# Appendix E Prospective Cohort Studies

The Health and Medicine Division (HMD) committee of the National Academies of Sciences, Engineering, and Medicine (NASEM) provided a list of longitudinal studies that may provide evidence on interventions to prevent age-related cognitive decline, MCI, and clinical Alzheimer’s-type dementia. We used Google search engine to locate, where available, the longitudinal study’s website, and where not available, academic sites or curated databases that provided a description of the study. (Some longitudinal studies are hosted or conducted primarily in countries where English is not the first language; descriptions for those studies were drawn from the associated publications in the table.) Study descriptions were used to confirm the prospective cohort study design, usually interested in determining incidence or risk factors, and that treatment was not assigned.

For each study, we iteratively searched PubMed using the study name and a key word (such as “cognitive impairment” and “dementia”) derived from the search algorithms in Appendix A to identify related publications. These example articles were compared to the general search results to try to identify gaps in the literature. No gaps were found. Articles that were examples of the type of publication derived from the prospective cohort study but excluded from this review are provided in the table below. The studies were excluded because treatment was not assigned and appropriate techniques to address selection bias were not employed in order to provide information on causal relationships.

Next, for each study we again iteratively searched PubMed using the study name and key words that identify an analytic method that may be applied to a prospective cohort study to simulate an experimental design by “assigning” exposure to the intervention, for example, “instrumental variable” (IV) or “Mendelian randomization.” No publications were identified using this method.

As can be seen in the cohort study descriptions, many of these prospective cohort studies have been generating data for decades. The derivative publications can number in the hundreds, possibly greater than 1000 articles per cohort study. Given the potentially large number of publications, which, based on our searches, did not rise to inclusion criteria due to study design (treatment was not assigned or appropriate techniques to address selection bias were not employed in order to provide information on causal relationships), we did not provide full bibliographies for each cohort study.

Appendix Table E1 Prospective cohort studies searched for relevant literature

Committee-suggested Cohort Studies Country | Cohort Study Description | Example of excluded publication derived from cohort study
3C (Three Cities Study) France | The Three-City Study (3C Study) is a population-based longitudinal study aiming to examine the relation between vascular diseases and dementia in adults 65 years and older. http://www.three-city-study.com/the-three-city-study.php | Ancelin ML, et al. Steroid and nonsteroidal anti-inflammatory drugs, cognitive decline, and dementia. Neurobiology of Aging, 2011, doi:10.1016/j.neurobiolaging.2011.09.038.
Adult Changes in Thought Study (ACT) US | ACT is made up of 3 cohorts. Current total enrollment is 4,960. Between 1994 and 1996, the study enrolled 2,581 participants. The purpose of this cohort study is to prospectively examine the incidence of AD and dementia, as well as risk factors for those conditions. https://www.maelstrom-research.org/mica/study/act | Gray SL, et al. Antioxidant vitamin supplement use and risk of dementia or Alzheimer’s disease in older adults. J Am Geriatr Soc. 2008 Feb;56(2):291–5.
Age, Gene/Environment Susceptibility – Reykjavik Study (AGES-RS) Iceland | The AGES will phenotype the surviving 12,000 members of the Reykjavik Study cohort (now 67 years and older) for quantitative traits related to diseases and conditions of old age, and collect genetic and other biologic specimens. http://www.hjartarannsokn.is/index.aspx?GroupId=346 | Sigurdur Sigurdsson, et.al. Brain tissue volumes in the general population of the elderly: The AGES-Reykjavik Study, NeuroImage, Volume 59, Issue 4, 15 February 2012, Pages 3862–3870, ISSN 1053-8119, http://dx.doi.org/10.1016/j.neuroimage.2011.11.024.
Atherosclerosis Risk in Communities (ARIC) US | The Atherosclerosis Risk in Communities Study (ARIC), sponsored by the National Heart, Lung, and Blood Institute (NHLBI) is a prospective epidemiologic study conducted in four U.S. The Cohort Component of the ARIC study began in 1987, and each of the four ARIC field centers randomly selected and recruited a cohort sample of approximately 4,000 individuals aged 45–64 from a defined population in their community. A total of 15,792 participants received an extensive examination, including medical, social, and demographic data. https://www2.cscc.unc.edu/aric/desc | Lutsey PL, et. al. 2016. Obstructive Sleep Apnea and 15-Year Cognitive Decline: The Atherosclerosis Risk in Communities (ARIC) Study. Sleep. 39(2):309–16. PubMed
Austrian Study of Stroke Prevention (ASPS) Austria | Community-based cohort study on vascular risk factors and brain structure and function in older adults. 2000 participants, 1000 with imaging, healthy population, aged 45 – 85 years old (non-English website) | Enzinger C, et al. Risk factors for progression of brain atrophy: 6-year follow up of the ASPS. Neurology, 2005
Baltimore Longitudinal Study of Aging (BLSA) US | The BLSA is a longitudinal study, with over 1300 participants currently and over 3100 since study inception. The aim of the study is to understand what is aging. Researchers measure physical and cognitive changes associated with aging in real time among a dedicated group of BLSA participants who come in for testing at regular intervals over the course of their lives. https://www.blsa.nih.gov/ | Beydoun MA, et al. Statins and serum cholesterol’s associations with incident dementia and mild cognitive impairment. Journal of epidemiology and community health. 2011;65(11):949–957. doi:10.1136/jech.2009.100826.
Cache County Study on Memory Health and Aging US | The study is designed to examine genetic and environmental factors associated with risk for Alzheimer’s disease and other forms of dementia. Started in 1995, the study enrolled 5,092 permanent residents of the county (90%), including approximately 800 individuals aged 85 years and older. The CCMS is a longitudinal investigation of aging and Alzheimer’s disease (AD) based in an exceptionally long-lived population residing in northern Utah. The elderly of Cache County have a longer life expectancy, higher educational attainment, and lower incidence of chronic disease (which can complicate the diagnosis of dementias) than other similar populations. http://www.usu.edu/epicenter/htm/studies/memorystudy | Peters M, et al. Neuropsychiatric symptoms as risk factors for progression from CIND to dementia: The Cache County Study. The American journal of geriatric psychiatry : official journal of the American Association for Geriatric Psychiatry. 2013;21(11):10.1016/j.jagp.2013.01.049. doi:10.1016/j.jagp.2013.01.049.
Cardiovascular Health Study (CHS) US | The Cardiovascular Health Study (CHS) is an NHLBI-funded observational study of risk factors for cardiovascular disease in adults 65 years or older. Starting in 1989, and continuing through 1999, participants underwent annual extensive clinical examinations. Measurements included traditional risk factors such as blood pressure and lipids as well as measures of subclinical disease, including echocardiography of the heart, carotid ultrasound, and cranial magnetic-resonance imaging (MRI). At six month intervals between clinic visits, and once clinic visits ended, participants were contacted by phone to ascertain hospitalizations and health status. The main outcomes are coronary heart disease (CHD), angina, heart failure (HF), stroke, transient ischemic attack (TIA), claudication, and mortality. Participants continue to be followed for these events. https://chs-nhlbi.org/ | Incidence of mild cognitive impairment in the Pittsburgh Cardiovascular Health Study–Cognition Study Oscar L. et. al. October 9, 2012, 79:15 1599–1606; published ahead of print September 26, 2012, doi:10.1212/WNL.0b013e31826e25f0:1526-632X
Chicago Health and Aging Project (CHAP) US | CHAP is a longitudinal population study of common chronic health problems of older persons, especially of risk factors for incident Alzheimer’s disease, in a biracial neighborhood of the south side of Chicago. http://www.alzrisk.org/cohort.aspx?cohortID=15&rfid=2 | Morris MC, et al. Dietary intake of antioxidant nutrients and the risk of incident Alzheimer disease in a biracial community study. JAMA. 2002 Jun 26;287(24):3230–7.
Coronary Artery Risk Development in Young Adults Study (CARDIA) US | The Coronary Artery Risk Development in Young Adults (CARDIA) Study is a study examining the development and determinants of clinical and subclinical cardiovascular disease and their risk factors. It began in 1985–6 with a group of 5115 black and white men and women aged 18–30 years. The participants were selected so that there would be approximately the same number of people in subgroups of race, gender, education (high school or less and more than high school) and age (18–24 and 25–30) in each of 4 centers: Birmingham, AL; Chicago, IL; Minneapolis, MN; and Oakland, CA. http://www.cardia.dopm.uab.edu/ | No relevant studies immediately found
Framingham Heart Study (note: Framingham cohorts include the Original, Offspring and Gen 3 cohorts) US | The objective of the Framingham Heart Study was to identify the common factors or characteristics that contribute to CVD by following its development over a long period of time in a large group of participants who had not yet developed overt symptoms of CVD or suffered a heart attack or stroke. The researchers recruited 5,209 men and women between the ages of 30 and 62 from the town of Framingham, Massachusetts. Since 1948, the subjects have continued to return to the study every two years for a detailed medical history, physical examination, and laboratory tests. In 1971, the Study enrolled a second generation - 5,124 of the original participants’ adult children and their spouses - to participate in similar examinations. In 1994, the need to establish a new study reflecting a more diverse community of Framingham was recognized, and the first Omni cohort of the Framingham Heart Study was enrolled. In April 2002 the Study entered a new phase, the enrollment of a third generation of participants, the grandchildren of the Original Cohort. In 2003, a second group of Omni participants was enrolled. https://www.framinghamheartstudy.org/ | Karakis I, et al. Association of Serum Vitamin D with the Risk of Incident Dementia and Subclinical Indices of Brain Aging: The Framingham Heart Study. J Alzheimers Dis. 2016. Epub 2016/02/19. doi: 10.3233/jad-150991. (PubMed ID Number: 26890771).
Health and Retirement Study (HRS) US | The University of Michigan Health and Retirement Study (HRS) is a longitudinal panel study that surveys a representative sample of approximately 20,000 people in America over the age of 50 every two years. http://hrsonline.isr.umich.edu/ | Saczynski JS, et al. Antidepressant Use and Cognitive Decline: The Health and Retirement Study. The American journal of medicine. 2015;128(7):739–746. doi:10.1016/j.amjmed.2015.01.007.
Health, Aging and Body Composition Study (Health ABC) US | The HEALTH ABC Study will characterize the extent of change in body composition in older men and women, identify clinical conditions accelerating these changes, and examine the health impact of these changes on strength, endurance, disability, and weight-related diseases of old age. The study population consists of 3,075 persons age 70–79 at baseline with about equal numbers of men and women. Thirty-three percent of the men are African-Americans as are 46% of the women. All persons in the study were selected to be free of disability in activities of daily living and free of functional limitation (defined as any difficulty walking a quarter of a mile or any difficulty walking up 10 steps without resting) at baseline. https://www.nia.nih.gov/research/intramural-research-program/dynamics-health-aging-and-body-composition-health-abc | No relevant studies immediately found
Honolulu-Asia Aging Study (HAAS) US | The Honolulu-Asia Aging Study (HAAS) is a longitudinal epidemiologic investigation of rates, risk factors, and neuropathologic abnormalities associated with cognitive decline and dementia in aged Japanese-American men. http://www.alzrisk.org/cohort.aspx?cohortID=3&rfid=5 | Taaffe, Dennis R., et al. “Physical activity, physical function, and incident dementia in elderly men: the Honolulu–Asia Aging Study.” The Journals of Gerontology Series A: Biological Sciences and Medical Sciences 63.5 (2008): 529–535.
Kame Project (a cohort study of Japanese Americans in King County, Washington) US | A large population-based prospective study of Japanese Americans in King County, Washington, who were followed from 1992 to 2001, as part of the Ni-Hon-Sea Project, a cross-cultural study of prevalence and incidence rates of Alzheimer’s disease and vascular dementia among Japanese populations living in Hiroshima, Japan; Oahu, Hawaii; and the metropolitan area of Seattle, Washington. http://www.alzrisk.org/cohort.aspx?cohortID=55&rfid=6 | Dai Q, et al. Fruit and Vegetable Juices and Alzheimer’s Disease: The Kame Project. The American journal of medicine. 2006;119(9):751–759. doi:10.1016/j.amjmed.2006.03.045.
Kungsholmen Project Sweden | The Kungsholmen Project is a longitudinal population-based study on ageing and dementia, carried out by the Stockholm Gerontology Research Center in collaboration with Aging Research Center (ARC), Karolinska Institutet. The project, which started in 1987, has gathered a 12-year long database and offers information on aging from a multidisciplinary perspective. http://www.kungsholmenproject.se/ | Qiu C, et. al. Decline in blood pressure over time and risk of dementia: a longitudinal study from the Kungsholmen project. Stroke 2004;35:1810–5.
Leisure World Cohort Study (note: the Leisure World is now extended as the 90+ Study) US | The Leisure World Cohort Study was established to study the effect of modifiable lifestyle practices on longevity and successful aging when all residents of a California retirement community (Leisure World Laguna Hills) were mailed a postal health survey in 1981. New residents who moved into the community after this date were mailed the survey in 1982, 1983, and 1985. Of the 22,910 residents, 13,978 (61%) completed the questionnaire. The population and cohort are mostly Caucasian, well educated, upper-middle class, and elderly. https://www.mind.uci.edu/research/90plus-study/ | Paganini-Hill, Annlia. “Hypertension and Dementia in the Elderly: The Leisure World Cohort Study.” International journal of hypertension 2012 (2011).
Lothian Birth Cohorts UK | The Lothian Birth Cohorts of 1921 and 1936 are follow-up studies of the Scottish Mental Surveys of 1932 and 1947. The surveys had, respectively, tested the intelligence of almost every child born in 1921 or 1936 and attending school in Scotland in the month of June in those years. Therefore, tracing, recruiting and re-testing people who had taken part in the Surveys offered a rare opportunity to examine the distribution and causes of cognitive ageing across most of the human life course. The studies described here were initially set up to study determinants of non-pathological cognitive ageing; i.e. the ageing of cognitive functions largely in the normal range, and not principally dementia or other pathological cognitive disordershttp://www.lothianbirthcohort.ed.ac.uk/ | No relevant studies immediately found
Mayo Clinic Study of Aging (MCSA) US | The MCSA is a population-based study that was designed to study incident mild cognitive impairment and dementia. The sampling frame included all persons aged 70–89 years who were residents of Olmsted County, Minnesota, as of October 1, 2004 (age- and sex-stratified random sample). The medical records of potential participants were formally reviewed prior to contact to exclude those with diagnoses of dementia, those in hospice care, or those considered to have conditions deemed imminently fatal. (Mayo Clinic does not appear to have a searchable site for this study.) | Vassilaki, Maria, et al. “Multimorbidity and risk of mild cognitive impairment.” Journal of the American Geriatrics Society 63.9 (2015): 1783–1790.
MEMENTO France | This cohort aims at studying the evolution of a variety of potentially early signs (cognitive complaints, deficit in some domain of cognition, psycho-behavioural disturbances, changes in imaging or biological markers) of Alzheimer’s disease and related dementia and to estimate the prognostic value of different markers (neuro-psychological, vascular, psychopathological, socio-educational, genetic, biological, neuro-imaging) on the progression to clinical dementia or severe cognitive deterioration stages, and then to death. http://www.memento-cohort.org/memento_web/Portals/0/Chercheurs/MEMENTO_Formulaire_AccesDonnees.pdf | No relevant studies immediately found
Minority Aging Research Study (MARS) US | The Minority Aging Research Study (MARS) began in 2004 and is a study of risk factors for cognitive decline in older Blacks. Participants are recruited from community-based organizations, churches, and senior-subsidized housing facilities; the catchment area is within that of MAP. Study participation requires agreeing to detailed annual clinical evaluations and cognitive testing. Between 2004 and 2007, >350 older persons enrolled in the study. https://www.rush.edu/services-treatments/alzheimers-disease-center/minority-aging-research-study | No relevant studies immediately found
Monongahela Valley Independent Elders Survey (MoVIES) US | The MoVIES project investigated various aspects of normal and abnormal aging. It also studied the incidence, risk factors, and outcome in late-life dementia, including Alzheimer’s disease, in a prospective community-based epidemiologic study for 15 years. The study cohort was drawn from a rural, largely blue-collar community in the mid-Monongahela Valley of Southwestern Pennsylvania. The original cohort of 1681 individuals aged 65+ years was assembled between 1987 and 1989 and was followed until 2002 with multi-stage clinical “Waves” of cognitive and risk factor screening. Screening waves were interspersed with multi-stage clinical evaluations to detect the presence of Alzheimer’s and other dementias. http://www.wpic.pitt.edu/research/dementia_epidemiology/Movies/MoviesHomePage.htm | No relevant studies immediately found
Monongahela-Youghiogheny Healthy Aging Team (MYHAT) US | The MYHAT project seeks to describe the distribution of Cognitive Impairment, No Dementia (CIND) and Mild Cognitive Impairment (MCI) and related entities, their associated features, their outcomes over time, and the predictors of these outcomes. An age-stratified random community sample of approximately 2,100 was recruited and screened using cognitive, functional, and other health-related measures to identify the non-demented who are cognitively impaired. Among them, we identified subgroups meeting operational criteria for MCI of amnestic and other varieties. http://www.wpic.pitt.edu/research/dementia_epidemiology/MYHAT/MYHATHomePage.htm | Hughes TF, et al. Independent and combined effects of cognitive and physical activity on incident MCI. Alzheimers and Dement. 2015 Nov; 11(11): 1377–84. doi: 10.1016/j.jalz.2014.11.007. (PMC4536189) Ganguli M, et al. Rates and risk factors for progression to incident dementia vary by age in population cohort. Neurology, 84(1):72–80. (PMC4336092)
Multi-Ethnic Study of Atherosclerosis (MESA) US | The MESA study examines the characteristics of subclinical cardiovascular disease (disease detected non-invasively before it has produced clinical signs and symptoms) and the risk factors that predict progression to clinically overt cardiovascular disease or progression of the subclinical disease. From July 2000 to January 2012, MESA is a prospective population-based sample of 6,814 asymptomatic men and women aged 45–84. Approximately 38 percent of the recruited participants are white, 28 percent African-American, 22 percent Hispanic, and 12 percent Asian, predominantly of Chinese descent. https://www.mesa-nhlbi.org/ | No relevant studies immediately found
Northern Manhattan Study (NOMAS) US | NOMAS)is a study of the population of Washington Heights in Northern Manhattan. The ongoing study, which began in 1990, is based in the Neurological Institute of Columbia Presbyterian Hospital, located in Washington Heights. NOMAS has enrolled over 4,400 people from the surrounding community. NOMAS is the first study of its kind to focus on stroke risk factors in whites, blacks, and Hispanics living in the same community. It is helping to fill gaps in our knowledge of stroke epidemiology in minority populations. http://columbianomas.org/ | No relevant studies immediately found
Nurses’ Health Study US | The Nurses’ Health Studies are among the largest prospective investigations into the risk factors for major chronic diseases in women. Starting with the original Nurses’ Health Study in 1976, the studies are now in their third generation with Nurses’ Health Study 3 (which is still enrolling male and female nurses) and count more than 275,000 participants. http://www.nurseshealthstudy.org/ | Devore, Elizabeth E., et al. “Dietary intakes of berries and flavonoids in relation to cognitive decline.” Annals of neurology 72.1 (2012): 135–143. Okereke, Olivia I., et al. “Plasma C-peptide levels and rates of cognitive decline in older, community-dwelling women without diabetes.” Psychoneuroendocrinology 33.4 (2008): 455–461.
Reasons for Geographic and Racial Differences in Stroke (REGARDS) US | REGARDS is an observational study of risk factors for stroke in adults 45 years or older. 30,239 participants were recruited between January 2003 and October 2007. They completed a telephone interview followed by an in-home physical exam. Measurements included traditional risk factors such as blood pressure and cholesterol levels, and an echocardiogram of the heart. At six month intervals, participants are contacted by phone to ask about stroke symptoms, hospitalizations and general health status. The study is ongoing and will follow participants for many years. http://www.regardsstudy.org/ | Zhu, Wenfei, et al. “Association Between Objectively Measured Physical Activity and Cognitive Function in Older Adults—The Reasons for Geographic and Racial Differences in Stroke Study.” Journal of the American Geriatrics Society 63.12 (2015): 2447–2454.
Religious Orders Study US | The Religious Orders Study is a collaborative study with Rush and other U.S. medical centers. It involves more than 1,100 older religious clergy (nuns, priests and brothers) who have agreed to medical and psychological evaluation each year and brain donation after death. Researchers are using information from the study to discover what changes in the brain are responsible for memory and movement problems. https://www.rush.edu/services-treatments/alzheimers-disease-center/religious-orders-study | Yu, Lei, et al. “The CETP I405V polymorphism is associated with an increased risk of Alzheimer’s disease.” Aging cell 11.2 (2012): 228–233.
Rochester Epidemiology Project (Olmsted County Study) US | The REP includes the medical records of all persons who have ever lived in Olmsted County, Minnesota between January 1, 1966 and the present, and who have given permission for their medical information to be used for research.[6] Those persons comprise more than 500,000 unique individuals and more than 6 million person years of follow-up through 2010. http://www.mayo.edu/research/centers-programs/rochester-epidemiology-project/overview | Savica, Rodolfo, et al. “Incidence of dementia with Lewy bodies and Parkinson disease dementia.” JAMA neurology 70.11 (2013): 1396–1402.
Rotterdam Study Netherlands | The Rotterdam Elderly Study is a prospective cohort study in the Ommoord district in the city of Rotterdam, the Netherlands. Recruitment started in January 1990. The main objectives of the Rotterdam Study were to investigate the risk factors of cardiovascular, neurological, ophthalmological and endocrine diseases in the elderly. Up to 2008, approximately 15,000 subjects aged 45 years or over have been recruited. http://www.epib.nl/research/ergo.htm | Ruitenberg A, et al. “Cerebral hypoperfusion and clinical onset of dementia: the Rotterdam Study.” Annals of neurology 57.6 (2005): 789–794. Engelhart, Marianne J., et al. “Inflammatory proteins in plasma and the risk of dementia: the Rotterdam study.” Archives of neurology 61.5 (2004): 668–672.
Rush Memory and Aging Project (MAP) US | The Rush MAP is a companion study that is more diverse in life experience make-up than ROS. Participants are older community-dwelling persons who are recruited and followed with nearly identical annual evaluations to ROS and all agree to donate brain, spinal cord, nerve and muscle to Rush investigator’s at the time of death. More than 1,350 participants have enrolled and are seen annually and have had up to 13 clinical evaluations. https://www.rush.edu/services-treatments/alzheimers-disease-center/radc-research/memory-and-aging-project-rush | Buchman, A. S., et al. “Total daily physical activity and the risk of AD and cognitive decline in older adults.” Neurology 78.17 (2012): 1323–1329.
The Sacramento Area Latino Study on Aging (SALSA) US | The Sacramento Area Latino Study on Aging (SALSA Study) project tracked the incidence of physical and cognitive impairment as well as dementia and cardiovascular diseases in elderly Latinos in the Sacramento, California, region. http://www.icpsr.umich.edu/icpsrweb/NACDA/studies/29323 | Haan, Mary N., et al. “Homocysteine, B vitamins, and the incidence of dementia and cognitive impairment: results from the Sacramento Area Latino Study on Aging.” The American journal of clinical nutrition 85.2 (2007): 511–517.
Singapore Longitudinal Ageing Study (SLAS) Singapore | Between September 2003 and December 2005, a whole population of older adults aged 55 years and above who were Singaporean residents in contiguous precincts in the South East region of Singapore were identified from a door–to–door census and invited to participate in the Singapore Longitudinal Ageing Study (SLAS). (No identifiable website) | Ng, Tze Pin, et al. “Metabolic Syndrome and the Risk of Mild Cognitive Impairment and Progression to Dementia: Follow-up of the Singapore Longitudinal Ageing Study Cohort.” JAMA neurology 73.4 (2016): 456–463.
Study of Osteoporotic Fractures (SOF) US | The multi-center Study of Osteoporotic Fractures (SOF) has 20 years of prospective data about osteoporosis that has served as the basis for many findings about osteoporosis and aging in women ≥ age 65. In addition to adjudication of fractures, SOF has tracked cases of incident breast cancer, and total and cause-specific mortalityhttp://sof.ucsf.edu/interface/ | Slinin, Yelena, et al. “Cystatin C and cognitive impairment 10 years later in older women.” The Journals of Gerontology Series A: Biological Sciences and Medical Sciences 70.6 (2015): 771–778.
The Sydney Memory and Ageing Study (Sydney MAS) Australia | The Sydney Memory and Ageing Study (Sydney MAS) began in 2005 to examine the clinical characteristics and prevalence of mild cognitive impairment (MCI) and related syndromes, and to determine the rate of change in cognitive function over time. It is one of the largest longitudinal studies of this kind in Australia. At the baseline assessment from 2005 to 2007, 1037 non-demented individuals aged 70–90 were recruited from two areas of Sydney, following a random approach to 8914 individuals on the electoral roll. They underwent detailed neuropsychological and medical assessments and donated a blood sample for clinical chemistry, proteomics and genomics. https://cheba.unsw.edu.au/project/sydney-memory-and-ageing-study | Heffernan, Megan, et al. “Alcohol Consumption and Incident Dementia: Evidence from the Sydney Memory and Ageing Study.” Journal of Alzheimer’s Disease Preprint (2016): 1–10. Sachdev, Perminder S., et al. “Risk profiles for mild cognitive impairment vary by age and sex: the Sydney Memory and Ageing Study.” The American Journal of Geriatric Psychiatry 20.10 (2012): 854–865.
UK Health and Lifestyle Study UK | The Health Survey for England (HSE) is an important annual survey looking at changes in the health and lifestyles of people all over the country. Around 8,000 adults and 2,000 children take part in the survey each year. Information is collected through an interview, and if participants agree, a visit from a specially trained nurse. The surveys, which have been carried out since 1991, provide regular information that cannot be obtained from other sources. https://www.ucl.ac.uk/hssrg/studies/hse | No relevant studies immediately found
Washington-Heights Inwood Columbia Aging Project (WHICAP) US | The Washington Heights-Hamilton Heights-Inwood Community Aging Project (WHICAP) is a community-based longitudinal study of aging and dementia among elderly, urban-dwelling residents. The project began enrolling patients in 1989 and has followed more than 5,900 residents over 65 years of age. The WHICAP study has enabled researchers to capture detailed information about the onset of dementia and how symptoms develop over time. http://www.alzrisk.org/cohort.aspx?cohortID=16&rfid=3 | Helzner, Elizabeth P., et al. “Contribution of vascular risk factors to the progression in Alzheimer disease.” Archives of neurology 66.3 (2009): 343–348.
Whitehall II Prospective Cohort Study UK | Whitehall II is a longitudinal, prospective cohort study of 10,308 women and men, all of whom were employed in the London offices of the British Civil Service at the time they were recruited to the study in 1985. The initial data collection included a clinical examination and self-report questionnaire. Research continues to explore the pathways and mechanisms through which social position influences health. The research group aims to build a causal model leading from social position through psychosocial and behavioural pathways to pathophysiological changes, sub-clinical markers of disease, functional change, and clinical disease. https://www.ucl.ac.uk/whitehallII | Singh-Manoux, Archana, et al. “Interleukin-6 and C-reactive protein as predictors of cognitive decline in late midlife.” Neurology 83.6 (2014): 486–493. Akbaraly, Tasnime N., et al. “Metabolic Syndrome Over 10 Years and Cognitive Functioning in Late Midlife The Whitehall II study.” Diabetes care 33.1 (2010): 84–89.