# Appendix D Excluded References

## Excluded References^1-243244-316317-523524-771772-920921-1037^

[Public title] Disease-modifying properties of lithium in the neurobiology of Alzheimer’s disease; [Scientific title] Disease-modifying properties of lithium in the neurobiology of Alzheimer’s disease: a double-blind, placebo-controlled prevention study in elderly patients with mild cognitive impairment. 2010. http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/416/CN-00738416/frame.html. Ineligible population
Nourishing Xin and Shen method improved mild cognitive impairment due to subcortical small vessel disease: a clinical study. [Chinese]. Zhongguo Zhong xi yi jie he za zhi Zhongguo Zhongxiyi jiehe zazhi = Chinese journal of integrated traditional and Western medicine / Zhongguo Zhong xi yi jie he xue hui, Zhongguo Zhong yi yan jiu yuan zhu ban. 2015 01 Jan;35(1):41–5. PMID 25790673. Inadequate follow up time25790673
Abbatecola AM, Lattanzio F, Molinari AM, . Rosiglitazone and cognitive stability in older individuals with type 2 diabetes and mild cognitive impairment. Diabetes Care. 2010 Aug;33(8):1706–11. PMID 20435794. Not cognitive decline prevention intervention20435794
Abdullah L, Luis C, Paris D, . Serum Abeta levels as predictors of conversion to mild cognitive impairment/Alzheimer disease in an ADAPT subcohort. Molecular Medicine. 2009 November–December;15(11–12):432–7. PMID 2010010064. Not cognitive decline prevention intervention19707525
Abelson JL, Khan S, Young EA, . Cognitive modulation of endocrine responses to CRH stimulation in healthy subjects. Psychoneuroendocrinology. 2010 Apr;35(3):451–9. PMID 19758763. Inadequate follow up time19758763
Abizanda P, Leon M, Dominguez-Martin L, . Effects of a short-term occupational therapy intervention in an acute geriatric unit. A randomized clinical trial. Maturitas. 2011 Jul;69(3):273–8. PMID 21600709. Inadequate follow up time21600709
Ablin JN, Clauw DJ, Lyden AK, . Effects of sleep restriction and exercise deprivation on somatic symptoms and mood in healthy adults. Clinical & Experimental Rheumatology. 2013 Nov–Dec;31(6 Suppl 79):S53–9. PMID 24373363. Inadequate follow up time24373363
Abner E, Schmitt F, Caban AH, . Dual cognitive screening for dementia: Preliminary case ascertainment in the antioxidant Alzheimer’s prevention (Preadvise) trial [Journal: Conference Abstract]. 2012. http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/737/CN-01004737/frame.html http://ac.els-cdn.com/S1552526012005171/1-s2.0-S1552526012005171-main.pdf?_tid=ae514dc0-c392-11e5-9470-00000aacb35f&acdnat=1453747226_8f943887053a7c81bbe29ad13ae1155d. Accessed on 4 suppl. 1 8. Not cognitive decline prevention intervention
Afzal S, Bojesen SE, Nordestgaard Bo G. Reduced 25-hydroxyvitamin D and risk of Alzheimer’s disease and vascular dementia. Alzheimer’s and Dementia. 2014 May;10(3):296–302. PMID 2014293602. Not cognitive decline prevention intervention
Agnew-Blais JC, Wassertheil-Smoller S, Kang JH, . Folate, vitamin B-6, and vitamin B-12 intake and mild cognitive impairment and probable dementia in the Women’s Health Initiative Memory Study. Journal of the Academy of Nutrition & Dietetics. 2015 Feb;115(2):231–41. PMID 25201007. Not cognitive decline prevention intervention25201007
Aguiar P, Monteiro L, Feres A, . Rivastigmine transdermal patch and physical exercises for Alzheimer’s disease: a randomized clinical trial. Current Alzheimer Research. 2014;11(6):532–7. PMID 24938502. Ineligible population24938502
Aguirre E, Spector A, Hoe J, . Maintenance Cognitive Stimulation Therapy (CST) for dementia: a single-blind, multi-centre, randomized controlled trial of Maintenance CST vs. CST for dementia. Trials [Electronic Resource]. 2010;11:46. PMID 20426866. Ineligible population20426866
Aisen PS, Gauthier S, Ferris SH, . Tramiprosate in mild-to-moderate Alzheimer’s disease - A randomized, double-blind, placebo-controlled, multi-centre study (the alphase study). Archives of Medical Science. 2011 February;7(1):102–11. PMID 2011142367. Ineligible population22291741
Akbaraly TN, Portet F, Fustinoni S, . Leisure activities and the risk of dementia in the elderly: results from the Three-City Study. Neurology. 2009 Sep 15;73(11):854–61. PMID 19752452. Not cognitive decline prevention intervention19752452
Akbaraly TN, Singh-Manoux A, Marmot MG, . Education attenuates the association between dietary patterns and cognition. Dementia & Geriatric Cognitive Disorders. 2009;27(2):147–54. PMID 19182482. Not cognitive decline prevention intervention19182482
Akhondzadeh S, Sabet MS, Harirchian MH, . Saffron in the treatment of patients with mild to moderate Alzheimer’s disease: a 16-week, randomized and placebo-controlled trial. Journal of Clinical Pharmacy & Therapeutics. 2010 Oct;35(5):581–8. PMID 20831681. Ineligible population20831681
Almaraz AC, Driver-Dunckley ED, Woodruff BK, . Efficacy of rivastigmine for cognitive symptoms in Parkinson disease with dementia. The neurologist. 2009 Jul;15(4):234–7. PMID 19590387. Ineligible study design19590387
Almeida OP, Yeap BB, Alfonso H, . Older men who use computers have lower risk of dementia. PLoS ONE [Electronic Resource]. 2012;7(8):e44239. PMID 22937167. Not cognitive decline prevention intervention22937167
Alosco ML, Spitznagel MB, Cohen R, . Decreases in body mass index after cardiac rehabilitation predict improved cognitive function in older adults with heart failure. Journal of the American Geriatrics Society. 2014 Nov;62(11):2215–6. PMID 25413196. Ineligible study design25413196
Altmann A, Tian L, Henderson VW, . Sex modifies the APOE-related risk of developing Alzheimer disease. Annals of Neurology. 2014 Apr;75(4):563–73. PMID 24623176. Ineligible study design24623176
Alvarez XA, Cacabelos R, Sampedro C, . Combination treatment in Alzheimer’s disease: results of a randomized, controlled trial with cerebrolysin and donepezil. Current Alzheimer Research. 2011 Aug;8(5):583–91. PMID 21679156. Ineligible population21679156
Alvarez XA, Sampedro C, Cacabelos R, . Reduced TNF-alpha and increased IGF-I levels in the serum of Alzheimer’s disease patients treated with the neurotrophic agent cerebrolysin. International Journal of Neuropsychopharmacology. 2009 Aug;12(7):867–72. PMID 19531281. Ineligible population19531281
Alves J, Alves-Costa F, Magalhaes R, . Cognitive stimulation for Portuguese older adults with cognitive impairment: a randomized controlled trial of efficacy, comparative duration, feasibility, and experiential relevance. American Journal of Alzheimer’s Disease & Other Dementias. 2014 Sep;29(6):503–12. PMID 24526760. Inadequate follow up time24526760
Amagase H, Sun B, Nance DM. Immunomodulatory effects of a standardized Lycium barbarum fruit juice in Chinese older healthy human subjects. Journal of Medicinal Food. 2009 Oct;12(5):1159–65. PMID 19857084. Inadequate follow up time19857084
Ambrosius WT, Sink KM, Foy CG, . The design and rationale of a multicenter clinical trial comparing two strategies for control of systolic blood pressure: the Systolic Blood Pressure Intervention Trial (SPRINT). Clinical Trials. 2014 Oct;11(5):532–46. PMID 24902920. Ineligible study design24902920
Amenta F, Carotenuto A, Fasanaro AM, . The ASCOMALVA trial: association between the cholinesterase inhibitor donepezil and the cholinergic precursor choline alphoscerate in Alzheimer’s disease with cerebrovascular injury: interim results. Journal of the Neurological Sciences. 2012 Nov 15;322(1–2):96–101. PMID 22959283. Ineligible population22959283
Amenta F, Carotenuto A, Fasanaro AM, . The ASCOMALVA (Association between the Cholinesterase Inhibitor Donepezil and the Cholinergic Precursor Choline Alphoscerate in Alzheimer’s Disease) Trial: interim results after two years of treatment. Journal of Alzheimer’s Disease. 2014;42 Suppl 3:S281–8. PMID 24898643. Ineligible population24898643
Amenta F, Carotenuto A, Fasanaro G, . Preliminary results of ASCOMALVA trial on the association of donepezil and choline alphoscerate in Alzheimer’s disease with associated cerebrovascular injury. [Italian] Studio sull’effetto dell’associazione tra l’inibitore delle colinesterasi donepezil e il precursore colinergico colina alfoscerato sui sintomi della malattia di Alzheimer con danno vascolare associato (ASCOMALVA). primi risultati. Giornale di Gerontologia. 2011 April;59(2):89–98. PMID 2011290156. Ineligible population
Amieva H, Stoykova R, Matharan F, . What aspects of social network are protective for dementia? Not the quantity but the quality of social interactions is protective up to 15 years later. Psychosomatic Medicine. 2010 Nov;72(9):905–11. PMID 20807876. Not cognitive decline prevention intervention20807876
Ancelin ML, Carriere I, Barberger-Gateau P, . Lipid lowering agents, cognitive decline, and dementia: The three-city study. Journal of Alzheimer’s Disease. 2012;30(3):629–37. PMID 2012367868. Not cognitive decline prevention intervention
Ancelin ML, Carriere I, Helmer C, . Steroid and nonsteroidal anti-inflammatory drugs, cognitive decline, and dementia. Neurobiology of Aging. 2012 Sep;33(9):2082–90. PMID 22071123. Not cognitive decline prevention intervention22071123
Andel R, Crowe M, Hahn EA, . Work-related stress may increase the risk of vascular dementia. Journal of the American Geriatrics Society. 2012 Jan;60(1):60–7. PMID 22175444. Ineligible population22175444
Andersen F, Viitanen M, Halvorsen DS, . The effect of stimulation therapy and donepezil on cognitive function in Alzheimer’s disease. A community based RCT with a two-by-two factorial design. BMC Neurology. 2012;12:59. PMID 22813231. Ineligible population22813231
Anderson S, White-Schwoch T, Choi HJ, . Training changes processing of speech cues in older adults with hearing loss. The effect of hearing loss on neural processing. 2015. Inadequate follow up time
Anderson S, White-Schwoch T, Parbery-Clark A, . Reversal of age-related neural timing delays with training. Proceedings of the National Academy of Sciences of the United States of America. 2013 Mar 12;110(11):4357–62. PMID 23401541. Inadequate follow up time23401541
Anderson-Hanley C, Arciero PJ, Brickman AM, . Exergaming and older adult cognition: a cluster randomized clinical trial. American Journal of Preventive Medicine. 2012 Feb;42(2):109–19. PMID 22261206. Inadequate follow up time22261206
Andreasen N, Simeoni M, Ostlund H, . First administration of the Fc-attenuated anti-beta amyloid antibody GSK933776 to patients with mild Alzheimer’s disease: A randomized, placebo-controlled study. PLoS ONE. 2015 19 Mar;10(3)PMID 2015879759. Ineligible population
Andreeva VA, Whegang-Youdom S, Touvier M, . Midlife dietary vitamin D intake and subsequent performance in different cognitive domains. Annals of Nutrition & Metabolism. 2014;65(1):81–9. PMID 25227981. No relevant outcomes reported25227981
Annweiler C, Ferland G, Barberger-Gateau P, . Vitamin K antagonists and cognitive impairment: results from a cross-sectional pilot study among geriatric patients. Journals of Gerontology Series A-Biological Sciences & Medical Sciences. 2015 Jan;70(1):97–101. PMID 25151653. Ineligible study design25151653
Annweiler C, Rolland Y, Schott AM, . Higher vitamin D dietary intake is associated with lower risk of alzheimer’s disease: a 7-year follow-up. Journals of Gerontology Series A-Biological Sciences & Medical Sciences. 2012 Nov;67(11):1205–11. PMID 22503994. Cohort study with inadequate sample size22503994
Anstey KJ, Bahar-Fuchs A, Herath P, . Body brain life: A randomized controlled trial of an online dementia risk reduction intervention in middle-aged adults at risk of Alzheimer’s disease. Alzheimer’s and Dementia: Translational Research and Clinical Interventions. 2015 14 Oct;1(1):72–80. PMID 2015440238. No relevant outcomes reported
Anstey KJ, Byles JE, Luszcz MA, . Cohort profile: The Dynamic Analyses to Optimize Ageing (DYNOPTA) project. International Journal of Epidemiology. 2010 Feb;39(1):44–51. PMID 19151373. Not cognitive decline prevention intervention19151373
Anton Alvarez X, Sampedro C, Cacabelos R, . Reduced TNF- and increased IGF-I levels in the serum of Alzheimer’s disease patients treated with the neurotrophic agent Cerebrolysin. International Journal of Neuropsychopharmacology. 2009 August;12(7):867–72. PMID 2009469772. Ineligible population19531281
Antonenko D, Floel A. Non-invasive brain stimulation in neurology: Transcranial direct current stimulation to enhance cognitive functioning. [German] Nichtinvasive Stimulationsverfahren in der Neurologie: Transkranielle Gleichstromstimulation zur kognitiven Funktionsverbesserung. Nervenarzt. 2016 01 Aug;87(8):838–45. PMID 610354183. Not available in English27167887
Apostolo JL, Cardoso DF, Rosa AI, . The effect of cognitive stimulation on nursing home elders: a randomized controlled trial. Journal of Nursing Scholarship. 2014 May;46(3):157–66. PMID 24597922. Ineligible population24597922
Apostolova LG, Babakchanian S, Hwang KS, . Ventricular enlargement and its clinical correlates in the imaging cohort from the ADCS MCI donepezil/vitamin E study. Alzheimer Disease & Associated Disorders. 2013 Apr–Jun;27(2):174–81. PMID 23694947. Cohort study with inadequate sample size23694947
Arab L, Biggs ML, O’Meara ES, . Gender differences in tea, coffee, and cognitive decline in the elderly: the Cardiovascular Health Study. Journal of Alzheimer’s Disease. 2011;27(3):553–66. PMID 21841254. Not cognitive decline prevention intervention21841254
Araki A, Iimuro S, Sakurai T, . Long-term multiple risk factor interventions in Japanese elderly diabetic patients: the Japanese Elderly Diabetes Intervention Trial--study design, baseline characteristics and effects of intervention. Geriatrics & gerontology international. 2012 Apr;12 Suppl 1:7–17. PMID 22435936. No relevant outcomes reported22435936
Araki T, Wake R, Miyaoka T, . The effects of combine treatment of memantine and donepezil on Alzheimer’s disease patients and its relationship with cerebral blood flow in the prefrontal area. International Journal of Geriatric Psychiatry. 2014 Sep;29(9):881–9. PMID 24436135. Ineligible population24436135
Arntzen KA, Schirmer H, Wilsgaard T, . Moderate wine consumption is associated with better cognitive test results: a 7 year follow up of 5033 subjects in the Tromso Study. Acta Neurologica Scandinavica. 2010;Supplementum.(190):23–9. PMID 20586731. Not cognitive decline prevention intervention20586731
Articus K, Baier M, Tracik F, . A 24-week, multicentre, open evaluation of the clinical effectiveness of the rivastigmine patch in patients with probable Alzheimer’s disease. International Journal of Clinical Practice. 2011 Jul;65(7):790–6. PMID 21645184. Ineligible population21645184
Athilingam P, Edwards JD, Valdes EG, . Computerized auditory cognitive training to improve cognition and functional outcomes in patients with heart failure: Results of a pilot study. Heart & Lung. 2015 Mar–Apr;44(2):120–8. PMID 25592205. Inadequate follow up time25592205
Au R, Seshadri S, Knox K, . The Framingham Brain Donation Program: neuropathology along the cognitive continuum. Current Alzheimer Research. 2012 Jul;9(6):673–86. PMID 22471865. Not cognitive decline prevention intervention22471865
Azhar ZM, Zubaidah JO, Norjan KO, . A pilot placebo-controlled, double-blind, and randomized study on the cognition-enhancing benefits of a proprietary chicken meat ingredient in healthy subjects. Nutrition Journal. 2013;12:121. PMID 23945213. Inadequate follow up time23945213
Bachinskaya N, Hoerr R, Ihl R. Alleviating neuropsychiatric symptoms in dementia: The effects of Ginkgo biloba extract EGb 761. Findings from a randomized controlled trial. Neuropsychiatric Disease and Treatment. 2011;7(1):209–15. PMID 2011559394. Ineligible population21573082
Baker LD, Asthana S, Cholerton BA, . Cognitive response to estradiol in postmenopausal women is modified by high cortisol. Neurobiology of Aging. 2012 Apr;33(4):829.e9–20. PMID 21855173. Inadequate follow up time21855173
Baker LD, Cross DJ, Minoshima S, . Insulin resistance and Alzheimer-like reductions in regional cerebral glucose metabolism for cognitively normal adults with prediabetes or early type 2 diabetes. Archives of Neurology. 2011 Jan;68(1):51–7. PMID 20837822. Inadequate follow up time20837822
Bakker A, Albert MS, Krauss G, . Response of the medial temporal lobe network in amnestic mild cognitive impairment to therapeutic intervention assessed by fMRI and memory task performance. NeuroImage: Clinical. 2015;7:688–98. PMID 2015830727. Inadequate follow up time25844322
Ballesteros S, Prieto A, Mayas J, . Brain training with non-action video games enhances aspects of cognition in older adults: a randomized controlled trial. Frontiers in aging neuroscience. 2014;6:277. Inadequate follow up time25352805
Ballesteros S, Prieto A, Mayas J, . Corrigendum: Brain training with non-action video games enhances aspects of cognition in older adults: a randomized controlled trial. Frontiers in aging neuroscience. 2015. Inadequate follow up time
Bamidis PD, Fissler P, Papageorgiou SG, . Gains in cognition through combined cognitive and physical training: the role of training dosage and severity of neurocognitive disorder. Frontiers in aging neuroscience. 2015;7. Inadequate follow up time25762930
Barban F, Annicchiarico R, Pantelopoulos S, . Protecting cognition from aging and Alzheimer’s disease: A computerized cognitive training combined with reminiscence therapy. International Journal of Geriatric Psychiatry. 2016 01 Apr;31(4):340–8. PMID 605331877. Inadequate follow up time26205305
Barnes DE, Mehling W, Wu E, . Preventing Loss of Independence through Exercise (PLIE): A pilot clinical trial in older adults with dementia. PLoS ONE. 2015 11 Feb;10(2)PMID 2015767557. Ineligible population
Barnes DE, Santos-Modesitt W, Poelke G, . The Mental Activity and eXercise (MAX) trial: a randomized controlled trial to enhance cognitive function in older adults. JAMA Internal Medicine. 2013 May 13;173(9):797–804. PMID 23545598. Inadequate follow up time23545598
Barnes DE, Yaffe K, Belfor N, . Computer-based cognitive training for mild cognitive impairment: results from a pilot randomized, controlled trial. Alzheimer Disease & Associated Disorders. 2009 Jul–Sep;23(3):205–10. PMID 19812460. Inadequate follow up time19812460
Barnes DE, Yaffe K, Byers AL, . Midlife vs late-life depressive symptoms and risk of dementia: differential effects for Alzheimer disease and vascular dementia. Archives of General Psychiatry. 2012 May;69(5):493–8. PMID 22566581. Not cognitive decline prevention intervention22566581
Barone P, Santangelo G, Morgante L, . A randomized clinical trial to evaluate the effects of rasagiline on depressive symptoms in non-demented Parkinson’s disease patients. European Journal of Neurology. 2015 Aug;22(8):1184–91. PMID 25962410. Inadequate follow up time25962410
Barrett DW, Gonzalez-Lima F. Transcranial infrared laser stimulation produces beneficial cognitive and emotional effects in humans. Neuroscience. 2013 Jan 29;230:13–23. PMID 23200785. Inadequate follow up time23200785
Barton DL, Burger K, Novotny PJ, . The use of Ginkgo biloba for the prevention of chemotherapy-related cognitive dysfunction in women receiving adjuvant treatment for breast cancer, N00C9. Supportive Care in Cancer. 2013 Apr;21(4):1185–92. PMID 23150188. Ineligible population23150188
Batty GD, Li Q, Huxley R, . Oral disease in relation to future risk of dementia and cognitive decline: prospective cohort study based on the Action in Diabetes and Vascular Disease: Preterax and Diamicron Modified-Release Controlled Evaluation (ADVANCE) trial. European Psychiatry: the Journal of the Association of European Psychiatrists. 2013 Jan;28(1):49–52. PMID 21964484. Not cognitive decline prevention intervention21964484
Bauer I, Hughes M, Rowsell R, . Omega-3 supplementation improves cognition and modifies brain activation in young adults. Human Psychopharmacology. 2014 Mar;29(2):133–44. PMID 24470182. Inadequate follow up time24470182
Baurle P, Suter A, Wormstall H. Safety and effectiveness of a traditional ginkgo fresh plant extract - results from a clinical trial. Forschende Komplementarmedizin (2006). 2009 Jun;16(3):156–61. PMID 19657199. Inadequate follow up time19657199
Bayer-Carter JL, Green PS, Montine TJ, . Diet intervention and cerebrospinal fluid biomarkers in amnestic mild cognitive impairment. Archives of Neurology. 2011 Jun;68(6):743–52. PMID 21670398. Inadequate follow up time21670398
Beck C, Fausett JK, Krukowski RA, . A randomized trial of a community-based cognitive intervention for obese senior adults. Journal of Aging & Health. 2013 Feb;25(1):97–118. PMID 23248351. Inadequate follow up time23248351
Beck SM, Ruge H, Schindler C, . Effects of Ginkgo biloba extract EGb 761 on cognitive control functions, mental activity of the prefrontal cortex and stress reactivity in elderly adults with subjective memory impairment-A randomized double-blind placebo-controlled trial. Human Psychopharmacology: Clinical and Experimental. 2016 May;31(3):227–42. PMID 2016-22663-005. Inadequate follow up time27147264
Belchior P, Marsiske M, Sisco SM, . Video game training to improve selective visual attention in older adults. Computers in human behavior. 2013;29(4):1318–24. Inadequate follow up time24003265
Bentley P, Driver J, Dolan RJ. Modulation of fusiform cortex activity by cholinesterase inhibition predicts effects on subsequent memory. Brain. 2009 Sep;132(Pt 9):2356–71. PMID 19605530. Not cognitive decline prevention intervention19605530
Bergamaschi S, Arcara G, Calza A, . One-year repeated cycles of cognitive training (CT) for Alzheimer’s disease. Aging-Clinical & Experimental Research. 2013 Aug;25(4):421–6. PMID 23784727. Ineligible population23784727
Bernick C, Cummings J, Raman R, . Age and rate of cognitive decline in Alzheimer disease: Implications for clinical trials. Archives of Neurology. 2012 July;69(7):901–5. PMID 2012409204. Ineligible population22431834
Berr C, Portet F, Carriere I, . Olive oil and cognition: results from the three-city study. Dementia & Geriatric Cognitive Disorders. 2009;28(4):357–64. PMID 19887798. Not cognitive decline prevention intervention19887798
Berry AS, Zanto TP, Clapp WC, . The influence of perceptual training on working memory in older adults. PLoS ONE [Electronic Resource]. 2010;5(7):e11537. PMID 20644719. Inadequate follow up time20644719
Bettermann K, Arnold AM, Williamson J, . Statins, risk of dementia, and cognitive function: secondary analysis of the ginkgo evaluation of memory study. Journal of Stroke & Cerebrovascular Diseases. 2012 Aug;21(6):436–44. PMID 21236699. Not cognitive decline prevention intervention21236699
Beydoun MA, Beason-Held LL, Kitner-Triolo MH, . Statins and serum cholesterol’s associations with incident dementia and mild cognitive impairment. Journal of Epidemiology & Community Health. 2011 Nov;65(11):949–57. PMID 20841372. Not cognitive decline prevention intervention20841372
Bickel H, Ander KH, Bronner M, . Reduction of long-term care dependence after an 8-year primary care prevention program for stroke and dementia: The INVADE trial. Journal of the American Heart Association. 2012 August;1(4)PMID 2013312020. Ineligible population
Bielak AA, Anstey KJ, Christensen H, . Activity engagement is related to level, but not change in cognitive ability across adulthood. Psychology & Aging. 2012 Mar;27(1):219–28. PMID 21806303. Not cognitive decline prevention intervention21806303
Biemans E, Hart HE, Rutten GE, . Cobalamin status and its relation with depression, cognition and neuropathy in patients with type 2 diabetes mellitus using metformin. Acta Diabetologica. 2015 Apr;52(2):383–93. PMID 25315630. Ineligible study design25315630
Bisby JA, King JA, Brewin CR, . Acute effects of alcohol on intrusive memory development and viewpoint dependence in spatial memory support a dual representation model. Biological Psychiatry. 2010 Aug 1;68(3):280–6. PMID 20202625. Inadequate follow up time20202625
Bjerke M, Kern S, Blennow K, . Cerebrospinal fluid fatty acid-binding protein 3 is related to dementia development in a population-based sample of older adult women followed for 8 years. Journal of Alzheimer’s Disease. 2016;49(3):733–41. PMID 20151037428. Ineligible study design
Blackburn DJ, Krishnan K, Fox L, . Prevention of Decline in Cognition after Stroke Trial (PODCAST): a study protocol for a factorial randomised controlled trial of intensive versus guideline lowering of blood pressure and lipids. Trials [Electronic Resource]. 2013;14:401. PMID 24266960. Ineligible population24266960
Blackwell T, Yaffe K, Laffan A, . Associations of objectively and subjectively measured sleep quality with subsequent cognitive decline in older community-dwelling men: the MrOS sleep study. Sleep. 2014;37(4):655–63. PMID 24899757. Ineligible study design24899757
Blasko I, Hinterberger M, Kemmler G, . Conversion from mild cognitive impairment to dementia: influence of folic acid and vitamin B12 use in the VITA cohort. Journal of Nutrition, Health & Aging. 2012 Aug;16(8):687–94. PMID 23076510. Not cognitive decline prevention intervention23076510
Blennow K, Zetterberg H, Rinne JO, . Effect of immunotherapy with bapineuzumab on cerebrospinal fluid biomarker levels in patients with mild to moderate Alzheimer disease. Archives of Neurology. 2012 Aug;69(8):1002–10. PMID 22473769. Ineligible population22473769
Block GA, Mitchel YB, Tobert JA, . Comparative effects of pravastatin and lovastatin on nighttime sleep and daytime performance. Clinical Cardiology. 1992 Oct;15(10):A24, 790. PMID 1395179. Inadequate follow up time1395179
Blumenthal JA, Smith PJ, Welsh-Bohmer K, . Can lifestyle modification improve neurocognition? Rationale and design of the ENLIGHTEN clinical trial. Contemporary Clinical Trials. 2013 Jan;34(1):60–9. PMID 23000080. Ineligible study design23000080
Boche D, Donald J, Love S, . Reduction of aggregated Tau in neuronal processes but not in the cell bodies after Abeta42 immunisation in Alzheimer’s disease. Acta Neuropathologica. 2010 Jul;120(1):13–20. PMID 20532897. Ineligible population20532897
Bohm M, Schumacher H, Leong D, . Systolic blood pressure variation and mean heart rate is associated with cognitive dysfunction in patients with high cardiovascular risk. Hypertension. 2015 Mar;65(3):651–61. PMID 25583157. Not cognitive decline prevention intervention25583157
Boissoneault J, Sklar A, Prather R, . Acute effects of moderate alcohol on psychomotor, set shifting, and working memory function in older and younger social drinkers. Journal of Studies on Alcohol & Drugs. 2014 Sep;75(5):870–9. PMID 25208205. Inadequate follow up time25208205
Boss HM, Van Schaik SM, Deijle IA, . A randomised controlled trial of aerobic exercise after transient ischaemic attack or minor stroke to prevent cognitive decline: the MoveIT study protocol. BMJ Open. 2014;4(12):e007065. PMID 25552615. Ineligible population25552615
Bossers WJ, Scherder EJ, Boersma F, . Feasibility of a combined aerobic and strength training program and its effects on cognitive and physical function in institutionalized dementia patients. A pilot study. PLoS ONE [Electronic Resource]. 2014;9(5):e97577. PMID 24844772. Inadequate follow up time24844772
Bouchard P. [Cognitive risks and HRT]. Revue du Praticien. 2010 Oct 20;60(8):1137–8. PMID 21197753. Not available in English21197753
Bowen ME. A prospective examination of the relationship between physical activity and dementia risk in later life. American Journal of Health Promotion. 2012 Jul–Aug;26(6):333–40. PMID 22747314. Not cognitive decline prevention intervention22747314
Bowen RL, Perry G, Xiong C, . A clinical study of lupron depot in the treatment of women with Alzheimer’s disease: preservation of cognitive function in patients taking an acetylcholinesterase inhibitor and treated with high dose lupron over 48 weeks. Journal of Alzheimer’s Disease. 2015;44(2):549–60. PMID 25310993. Ineligible population25310993
Boyle PA, Buchman AS, Barnes LL, . Effect of a purpose in life on risk of incident Alzheimer disease and mild cognitive impairment in community-dwelling older persons. Archives of General Psychiatry. 2010 Mar;67(3):304–10. PMID 20194831. Not cognitive decline prevention intervention20194831
Boyle PA, Buchman AS, Wilson RS, . Association of muscle strength with the risk of Alzheimer disease and the rate of cognitive decline in community-dwelling older persons. Archives of Neurology. 2009 November;66(11):1339–44. PMID 2009598988. Not cognitive decline prevention intervention19901164
Bozoki A, Radovanovic M, Winn B, . Effects of a computer-based cognitive exercise program on age-related cognitive decline. Archives of Gerontology & Geriatrics. 2013 Jul–Aug;57(1):1–7. PMID 23542053. Inadequate follow up time23542053
Brainin M, Matz K, Nemec M, . Prevention of poststroke cognitive decline: ASPIS - a multicenter, randomized, observer-blind, parallel group clinical trial to evaluate multiple lifestyle interventions - study design and baseline characteristics. International Journal of Stroke. 2015 01 Jun;10(4):627–35. PMID 2014768731. Ineligible population24206541
Braun AK, Kubiak T, Kuntsche J, . SGS: a structured treatment and teaching programme for older patients with diabetes mellitus--a prospective randomised controlled multi-centre trial. Age & Ageing. 2009 Jul;38(4):390–6. PMID 19454403. No relevant outcomes reported19454403
Breitner JCS, Haneuse SJPA, Walker R, . Risk of dementia and AD with prior exposure to NSAIDs in an elderly community-based cohort. Neurology. 2009 02 Jun;72(22):1899–905. PMID 2009338455. Not cognitive decline prevention intervention19386997
Brown AK, Liu-Ambrose T, Tate R, . The effect of group-based exercise on cognitive performance and mood in seniors residing in intermediate care and self-care retirement facilities: a randomised controlled trial. British Journal of Sports Medicine. 2009 Aug;43(8):608–14. PMID 18927162. Ineligible population18927162
Brown D, Spanjers K, Atherton N, . Development of an exercise intervention to improve cognition in people with mild to moderate dementia: Dementia And Physical Activity (DAPA) Trial, registration ISRCTN32612072. Physiotherapy (United Kingdom). 2015 01 Jun;101(2):126–34. PMID 2015778040. Ineligible population
Brown ES, Zaidel L, Allen G, . Effects of lamotrigine on hippocampal activation in corticosteroid-treated patients. Journal of Affective Disorders. 2010 November;126(3):415–9. PMID 2010547628. Ineligible population20580827
Brown PD, Pugh S, Laack NN, . Memantine for the prevention of cognitive dysfunction in patients receiving whole-brain radiotherapy: a randomized, double-blind, placebo-controlled trial. Neuro-Oncology. 2013 Oct;15(10):1429–37. PMID 23956241. Ineligible population23956241
Bruce J, Hancock L, Roberg B, . Impact of armodafinil on cognition in multiple sclerosis: a randomized, double-blind crossover pilot study. Cognitive & Behavioral Neurology. 2012 Sep;25(3):107–14. PMID 22960434. Ineligible population22960434
Brunetti V, Losurdo A, Testani E, . Rivastigmine for refractory REM behavior disorder in mild cognitive impairment. Current Alzheimer Research. 2014 Mar;11(3):267–73. PMID 24597506. No relevant outcomes reported24597506
Buchman AS, Boyle PA, Yu L, . Total daily physical activity and the risk of AD and cognitive decline in older adults. Neurology. 2012 Apr 24;78(17):1323–9. PMID 22517108. Not cognitive decline prevention intervention22517108
Buecking B, Struewer J, Waldermann A, . What determines health-related quality of life in hip fracture patients at the end of acute care?--a prospective observational study. Osteoporosis International. 2014 Feb;25(2):475–84. PMID 23783644. Ineligible population23783644
Burstein AH, Grimes I, Galasko DR, . Effect of TTP488 in patients with mild to moderate Alzheimer’s disease. BMC Neurology. 2014 January 15;14(1)PMID 2015890655. Ineligible population
Buschert VC, Friese U, Teipel SJ, . Effects of a newly developed cognitive intervention in amnestic mild cognitive impairment and mild Alzheimer’s disease: a pilot study. Journal of Alzheimer’s Disease. 2011;25(4):679–94. PMID 21483095. Ineligible population21483095
Byeon H, Lee Y, Lee SY, . Association of alcohol drinking with verbal and visuospatial memory impairment in older adults: Clinical Research Center for Dementia of South Korea (CREDOS) study. International Psychogeriatrics. 2015 Mar;27(3):455–61. PMID 25119654. Inadequate follow up time25119654
Cadar D, Pikhart H, Mishra G, . The role of lifestyle behaviors on 20-year cognitive decline. Journal of Aging Research. 2012;2012 (no pagination)(304014)PMID 2012621473. Not cognitive decline prevention intervention
Cancela JM, Vila Suarez MH, Vasconcelos J, . Efficacy of brain gym training on the cognitive performance and fitness level of active older adults: A preliminary study. Journal of Aging and Physical Activity. 2015 Oct;23(4):653–8. PMID 2015-49570-012. Inadequate follow up time25642951
Cao C, Loewenstein DA, Lin X, . High Blood caffeine levels in MCI linked to lack of progression to dementia. Journal of Alzheimer’s Disease. 2012;30(3):559–72. PMID 22430531. Not cognitive decline prevention intervention22430531
Caramelli P, Laks J, Palmini AL, . Effects of galantamine and galantamine combined with nimodipine on cognitive speed and quality of life in mixed dementia: a 24-week, randomized, placebo-controlled exploratory trial (the REMIX study). Arquivos de Neuro-Psiquiatria. 2014 Jun;72(6):411–7. PMID 24964105. Ineligible population24964105
Carlson MC, Erickson KI, Kramer AF, . Evidence for neurocognitive plasticity in at-risk older adults: the experience corps program. The journals of gerontology. 2009 Dec;Series A, Biological sciences and medical sciences. 64(12):1275–82. PMID 19692672. No relevant outcomes reported19692672
Carlsson CM, Nondahl DM, Klein BE, . Increased atherogenic lipoproteins are associated with cognitive impairment: effects of statins and subclinical atherosclerosis. Alzheimer Disease & Associated Disorders. 2009 Jan–Mar;23(1):11–7. PMID 19266697. Ineligible study design19266697
Carretti B, Borella E, Fostinelli S, . Benefits of training working memory in amnestic mild cognitive impairment: specific and transfer effects. International Psychogeriatrics. 2013 Apr;25(4):617–26. PMID 23253363. Inadequate follow up time23253363
Carriere I, Fourrier-Reglat A, Dartigues JF, . Drugs with anticholinergic properties, cognitive decline, and dementia in an elderly general population: the 3-city study. Archives of Internal Medicine. 2009 Jul 27;169(14):1317–24. PMID 19636034. Not cognitive decline prevention intervention19636034
Casoli T, Giuli C, Balietti M, . Effect of cognitive training on the expression of brain-derived neurotrophic factor in lymphocytes of mild cognitive impairment patients. Rejuvenation Research. 2014 Apr;17(2):235–8. PMID 24127698. Inadequate follow up time24127698
Cereda E, Sacchi MC, Malavazos AE. Central obesity and increased risk of dementia more than three decades later. Neurology. 2009 Mar 17;72(11):1030–1; author reply 1. PMID 19289749. Not cognitive decline prevention intervention19289749
Cervellati C, Trentini A, Romani A, . Serum paraoxonase and arylesterase activities of paraoxonase-1 (PON-1), mild cognitive impairment, and 2-year conversion to dementia: A pilot study. Journal of Neurochemistry. 2015 Oct;135(2):395–401. PMID 26178739. Not cognitive decline prevention intervention26178739
Chan A, Paskavitz J, Remington R, . Efficacy of a vitamin/nutriceutical formulation for early-stage Alzheimer’s disease: A 1-year, open-label pilot study with an 16-month caregiver extension. American Journal of Alzheimer’s Disease and other Dementias. 2009 December–January;23(6):571–85. PMID 2009009400. Ineligible population
Chang M, Jonsson PV, Snaedal J, . The effect of midlife physical activity on cognitive function among older adults: AGES--Reykjavik Study. Journals of Gerontology Series A-Biological Sciences & Medical Sciences. 2010 Dec;65(12):1369–74. PMID 20805238. Ineligible study design20805238
Chang SL, Tsai AC. Gender differences in the longitudinal associations of depressive symptoms and leisure-time physical activity with cognitive decline in > 57 year-old Taiwanese. Preventive Medicine. 2015 August 01;77:68–73. PMID 2015071830. Not cognitive decline prevention intervention25964077
Chang YK, Etnier JL. Exploring the dose-response relationship between resistance exercise intensity and cognitive function. Journal of Sport & Exercise Psychology. 2009 Oct;31(5):640–56. PMID 20016113. Inadequate follow up time20016113
Chao TF, Liu CJ, Chen SJ, . Statins and the risk of dementia in patients with atrial fibrillation: A nationwide population-based cohort study. International Journal of Cardiology. 2015 23 Jul;196:91–7. PMID 2015217508. Not cognitive decline prevention intervention26080283
Chen CL, Ikram K, Anqi Q, . The NeuroAiD II (MLC901) in vascular cognitive impairment study (NEURITES). Cerebrovascular Diseases. 2013;35 Suppl 1:23–9. PMID 23548916. Ineligible population23548916
Chen PY, Liu SK, Chen CL, . Long-term statin use and dementia risk in Taiwan. Journal of Geriatric Psychiatry & Neurology. 2014 Sep;27(3):165–71. PMID 24578458. Not cognitive decline prevention intervention24578458
Chen S, Yao X, Liang Y, . Alzheimer’s disease treated with combined therapy based on nourishing marrow and reinforcing Qi. Journal of Traditional Chinese Medicine. 2015 Jun;35(3):255–9. PMID 26237827. Ineligible population26237827
Cheng Y, Wang YJ, Yan JC, . Effects of carotid artery stenting on cognitive function in patients with mild cognitive impairment and carotid stenosis. Experimental and Therapeutic Medicine. 2013 April;5(4):1019–24. PMID 2013144752. Cohort study with inadequate sample size23596467
Cheng Y, Wu W, Feng W, . The effects of multi-domain versus single-domain cognitive training in non-demented older people: a randomized controlled trial. BMC Medicine. 2012;10:30. PMID 22453114. Inadequate follow up time22453114
Cherbuin N, Anstey KJ. The Mediterranean diet is not related to cognitive change in a large prospective investigation: the PATH Through Life study. American Journal of Geriatric Psychiatry. 2012 Jul;20(7):635–9. PMID 21937919. Not cognitive decline prevention intervention21937919
Cherrier MM, Anderson K, David D, . A randomized trial of cognitive rehabilitation in cancer survivors. Life Sciences. 2013 Oct 17;93(17):617–22. PMID 24012579. Ineligible population24012579
Chiu WC, Ho WC, Lin MH, . Angiotension receptor blockers reduce the risk of dementia. Journal of Hypertension. 2014 Apr;32(4):938–47. PMID 24406780. Not cognitive decline prevention intervention24406780
Choi SH, Park KW, Na DL, . Tolerability and efficacy of memantine add-on therapy to rivastigmine transdermal patches in mild to moderate Alzheimer’s disease: a multicenter, randomized, open-label, parallel-group study. Current Medical Research & Opinion. 2011 Jul;27(7):1375–83. PMID 21561398. Ineligible population21561398
Chou CY, Chou YC, Chou YJ, . Statin use and incident dementia: a nationwide cohort study of Taiwan. International Journal of Cardiology. 2014 May 1;173(2):305–10. PMID 24681022. Ineligible study design24681022
Choudhary P, Lonnen K, Emery CJ, . Comparing hormonal and symptomatic responses to experimental hypoglycaemia in insulin- and sulphonylurea-treated Type 2 diabetes. Diabetic Medicine. 2009 Jul;26(7):665–72. PMID 19573114. No relevant outcomes reported19573114
Christopher MS, Jacob KL, Neuhaus EC, . Cognitive and behavioral changes related to symptom improvement among patients with a mood disorder receiving intensive cognitive-behavioral therapy. Journal of Psychiatric Practice. 2009 Mar;15(2):95–102. PMID 19339843. Inadequate follow up time19339843
Chu DC, Fox KR, Chen LJ, . Components of late-life exercise and cognitive function: an 8-year longitudinal study. Prevention Science. 2015 May;16(4):568–77. PMID 25297968. No relevant outcomes reported25297968
Chuang CS, Lin CL, Lin MC, . Decreased prevalence of dementia associated with statins: A national population-based study. European Journal of Neurology. 2015 01 Jun;22(6):912–8. PMID 2015971469. Not cognitive decline prevention intervention24635778
Chuang YF, Breitner JC, Chiu YL, . Use of diuretics is associated with reduced risk of Alzheimer’s disease: the Cache County Study. Neurobiology of Aging. 2014 Nov;35(11):2429–35. PMID 24910391. Ineligible study design24910391
Ciarmiello A, Gaeta MC, Benso F, . FDG-PET in the evaluation of brain metabolic changes induced by cognitive stimulation in aMCI subjects. Current Radiopharmaceuticals. 2015 01 Jun;8(1):69–75. PMID 2015110096. Inadequate follow up time25925343
Clare L, Linden DE, Woods RT, . Goal-oriented cognitive rehabilitation for people with early-stage Alzheimer disease: a single-blind randomized controlled trial of clinical efficacy. American Journal of Geriatric Psychiatry. 2010 Oct;18(10):928–39. PMID 20808145. Ineligible population20808145
Claxton A, Baker LD, Hanson A, . Long-acting intranasal insulin detemir improves cognition for adults with mild cognitive impairment or early-stage Alzheimer’s disease dementia.[Erratum appears in J Alzheimers Dis. 2015;45(4):1269–70; PMID: 25869922]. Journal of Alzheimer’s Disease. 2015;44(3):897–906. PMID 25374101. Ineligible population25374101
Claxton A, Baker LD, Hanson A, . Long-acting intranasal insulin detemir improves cognition for adults with mild cognitive impairment or early-stage Alzheimer’s Disease dementia. Journal of Alzheimer’s Disease. 2015;44(3):897–906. PMID 2015740466. Ineligible population
Claxton A, Baker LD, Wilkinson CW, . Sex and ApoE genotype differences in treatment response to two doses of intranasal insulin in adults with mild cognitive impairment or Alzheimer’s disease. Journal of Alzheimer’s Disease. 2013;35(4):789–97. PMID 23507773. Ineligible population23507773
Colcombe SJ, Kramer AF, McAuley E, . Neurocognitive aging and cardiovascular fitness: recent findings and future directions. Journal of Molecular Neuroscience. 2004;24(1):9–14. PMID 15314244. Ineligible study design15314244
Collins N, Sachs-Ericsson N, Preacher KJ, . Smoking increases risk for cognitive decline among community-dwelling older Mexican Americans. American Journal of Geriatric Psychiatry. 2009 Nov;17(11):934–42. PMID 20104052. Not cognitive decline prevention intervention20104052
Collins R, Armitage J, Parish S, . MRC/BHF Heart Protection Study of cholesterol-lowering with simvastatin in 5963 people with diabetes: a randomised placebo-controlled trial. Lancet. 2003 Jun 14;361(9374):2005–16. PMID 12814710. No relevant outcomes reported12814710
Concha JB, Kravitz HM, Chin MH, . Review of type 2 diabetes management interventions for addressing emotional well-being in Latinos. Diabetes Educator. 2009 Nov–Dec;35(6):941–58. PMID 19773526. Ineligible study design19773526
Cooper ZD, Foltin RW, Hart CL, . A human laboratory study investigating the effects of quetiapine on marijuana withdrawal and relapse in daily marijuana smokers. Addiction Biology. 2013 Nov;18(6):993–1002. PMID 22741619. Inadequate follow up time22741619
Cordasco KM, Asch SM, Bell DS, . A low-literacy medication education tool for safety-net hospital patients. American Journal of Preventive Medicine. 2009 Dec;37(6 Suppl 1):S209–16. PMID 19896021. No relevant outcomes reported19896021
Cornelli U. Treatment of Alzheimer’s disease with a cholinesterase inhibitor combined with antioxidants. Neurodegenerative Diseases. 2010;7(1–3):193–202. PMID 20224285. Ineligible population20224285
Corsentino EA, Collins N, Sachs-Ericsson N, . Religious attendance reduces cognitive decline among older women with high levels of depressive symptoms. Journals of Gerontology Series A-Biological Sciences & Medical Sciences. 2009 Dec;64(12):1283–9. PMID 19675176. Not cognitive decline prevention intervention19675176
Cote S, Carmichael PH, Verreault R, . Nonsteroidal anti-inflammatory drug use and the risk of cognitive impairment and Alzheimer’s disease. Alzheimer’s & Dementia. 2012 May;8(3):219–26. PMID 22546354. Not cognitive decline prevention intervention22546354
Cotroneo AM, Castagna A, Putignano S, . Effectiveness and safety of citicoline in mild vascular cognitive impairment: the IDEALE study. Clinical Interventions In Aging. 2013;8:131–7. PMID 23403474. Ineligible population23403474
Craft S, Baker LD, Montine TJ, . Intranasal insulin therapy for Alzheimer disease and amnestic mild cognitive impairment: a pilot clinical trial. Archives of Neurology. 2012 Jan;69(1):29–38. PMID 21911655. Ineligible population21911655
Craik FI, Winocur G, Palmer H, . Cognitive rehabilitation in the elderly: effects on memory. Journal of the International Neuropsychological Society. 2007 Jan;13(1):132–42. PMID 17166312. Ineligible study design17166312
Crane PK, Gibbons LE, Arani K, . Midlife use of written Japanese and protection from late life dementia. Epidemiology. 2009 Sep;20(5):766–74. PMID 19593152. Not cognitive decline prevention intervention19593152
Creavin ST, Gallacher J, Pickering J, . High caloric intake, poor cognition and dementia: the Caerphilly Prospective Study. European Journal of Epidemiology. 2012 Mar;27(3):197–203. PMID 22392589. Not cognitive decline prevention intervention22392589
Crichton GE, Elias MF, Dore GA, . Measurement-to-measurement blood pressure variability is related to cognitive performance: the Maine Syracuse study. Hypertension. 2014 Nov;64(5):1094–101. PMID 25156168. No relevant outcomes reported25156168
Cronberg T, Lilja G, Horn J, . Neurologic Function and Health-Related Quality of Life in Patients Following Targeted Temperature Management at 33degreeC vs 36degreeC After Out-of-Hospital Cardiac Arrest: A Randomized Clinical Trial. JAMA Neurology. 2015 Jun;72(6):634–41. PMID 25844993. Ineligible population25844993
Cukierman-Yaffe T, Anderson C, Teo K, . Dysglycemia and Cognitive Dysfunction and Ill Health in People With High CV Risk: Results From the ONTARGET/TRANSCEND Studies. Journal of Clinical Endocrinology & Metabolism. 2015 Jul;100(7):2682–9. PMID 26020764. Not cognitive decline prevention intervention26020764
Cukierman-Yaffe T, Gerstein HC, Williamson JD, . Relationship between baseline glycemic control and cognitive function in individuals with type 2 diabetes and other cardiovascular risk factors: the action to control cardiovascular risk in diabetes-memory in diabetes (ACCORD-MIND) trial. Diabetes Care. 2009 Feb;32(2):221–6. PMID 19171735. Not cognitive decline prevention intervention19171735
Cummings J, Froelich L, Black SE, . Randomized, double-blind, parallel-group, 48-week study for efficacy and safety of a higher-dose rivastigmine patch (15 vs. 10 cm) in Alzheimer’s disease. Dementia and Geriatric Cognitive Disorders. 2012 July;33(5):341–53. PMID 2012461797. Ineligible population22796905
Cummings JL, Lyketsos CG, Peskind ER, . Effect of Dextromethorphan-Quinidine on Agitation in Patients With Alzheimer Disease Dementia: A Randomized Clinical Trial. JAMA. 2015 Sep 22–29;314(12):1242–54. PMID 26393847. Ineligible population26393847
Dahl A, Hassing LB, Fransson E, . Being overweight in midlife is associated with lower cognitive ability and steeper cognitive decline in late life. Journals of Gerontology Series A-Biological Sciences & Medical Sciences. 2010 Jan;65(1):57–62. PMID 19349594. Ineligible population19349594
Damoiseaux JS, Prater KE, Miller BL, . Functional connectivity tracks clinical deterioration in Alzheimer’s disease. Neurobiology of Aging. 2012 April;33(4):828.e19–e30. PMID 2012085742. Ineligible population
Dangour AD, Allen E, Elbourne D, . Fish consumption and cognitive function among older people in the UK: baseline data from the OPAL study. Journal of Nutrition, Health & Aging. 2009 Mar;13(3):198–202. PMID 19262951. Not cognitive decline prevention intervention19262951
Danhauer SC, Legault C, Bandos H, . Positive and negative affect, depression, and cognitive processes in the Cognition in the Study of Tamoxifen and Raloxifene (Co-STAR) Trial. Aging Neuropsychology & Cognition. 2013;20(5):532–52. PMID 23237718. No relevant outcomes reported23237718
Dannhauser TM, Cleverley M, Whitfield TJ, . A complex multimodal activity intervention to reduce the risk of dementia in mild cognitive impairment--ThinkingFit: pilot and feasibility study for a randomized controlled trial. BMC Psychiatry. 2014;14:129. PMID 24886353. Inadequate follow up time24886353
Danthiir V, Burns NR, Nettelbeck T, . The older people, omega-3, and cognitive health (EPOCH) trial design and methodology: a randomised, double-blind, controlled trial investigating the effect of long-chain omega-3 fatty acids on cognitive ageing and wellbeing in cognitively healthy older adults. Nutrition Journal. 2011;10:117. PMID 22011460. Ineligible study design22011460
Davis JL, Rhudy JL, Pruiksma KE, . Physiological predictors of response to exposure, relaxation, and rescripting therapy for chronic nightmares in a randomized clinical trial. Journal of Clinical Sleep Medicine. 2011 Dec 15;7(6):622–31. PMID 22171201. Ineligible population22171201
de Andrade LP, Gobbi LT, Coelho FG, . Benefits of multimodal exercise intervention for postural control and frontal cognitive functions in individuals with Alzheimer’s disease: a controlled trial. Journal of the American Geriatrics Society. 2013 Nov;61(11):1919–26. PMID 24219193. Ineligible population24219193
de Bruijn RF, Bos MJ, Portegies ML, . The potential for prevention of dementia across two decades: the prospective, population-based Rotterdam Study. BMC Medicine. 2015;13:132. PMID 26195085. Not cognitive decline prevention intervention26195085
de Bruijn RF, Schrijvers EM, de Groot KA, . The association between physical activity and dementia in an elderly population: the Rotterdam Study.[Erratum appears in Eur J Epidemiol. 2013 May;28(5):447–8]. European Journal of Epidemiology. 2013 Mar;28(3):277–83. PMID 23385659. Ineligible study design23385659
De Bruijn RFAG, Schrijvers EMC, De Groot KA, . The association between physical activity and dementia in an elderly population: The Rotterdam Study. European Journal of Epidemiology. 2013 March;28(3):277–83. PMID 2013314732. Not cognitive decline prevention intervention23385659
de Gobbi Porto FH, Coutinho AMN, de Sa Pinto AL, . Effects of aerobic training on cognition and brain glucose metabolism in subjects with mild cognitive impairment. Journal of Alzheimer’s Disease. 2015;46(3):747–60. PMID 2015-57104-018. Ineligible study design
de Jong FJ, Masaki K, Chen H, . Thyroid function, the risk of dementia and neuropathologic changes: the Honolulu-Asia aging study. Neurobiology of Aging. 2009 Apr;30(4):600–6. PMID 17870208. Not cognitive decline prevention intervention17870208
de Koning EJ, van Schoor NM, Penninx BW, . Vitamin D supplementation to prevent depression and poor physical function in older adults: Study protocol of the D-Vitaal study, a randomized placebo-controlled clinical trial. BMC Geriatrics. 2015;15:151. PMID 26585952. No relevant outcomes reported26585952
Dean AJ, Bellgrove MA, Hall T, . Effects of vitamin D supplementation on cognitive and emotional functioning in young adults--a randomised controlled trial. PLoS ONE [Electronic Resource]. 2011;6(11):e25966. PMID 22073146. Inadequate follow up time22073146
Defina LF, Willis BL, Radford NB, . The association between midlife cardiorespiratory fitness levels and later-life dementia: a cohort study.[Summary for patients in Ann Intern Med. 2013 Feb 5;158(3):I-36; PMID: 23381057]. Annals of Internal Medicine. 2013 Feb 5;158(3):162–8. PMID 23381040. Not cognitive decline prevention intervention23381040
DeHaven MJ, Ramos-Roman MA, Gimpel N, . The GoodNEWS (Genes, Nutrition, Exercise, Wellness, and Spiritual Growth) Trial: a community-based participatory research (CBPR) trial with African-American church congregations for reducing cardiovascular disease risk factors--recruitment, measurement, and randomization.[Erratum appears in Contemp Clin Trials. 2012 Nov;33(6):1321 Note: Duval, Julie [corrected to Duvahl, Julie]]. Contemporary Clinical Trials. 2011 Sep;32(5):630–40. PMID 21664298. No relevant outcomes reported21664298
Dersu, II, Spencer HT, Grigorian PA, . The effect of mydriatic solutions on cognitive function. Seminars in Ophthalmology. 2015 Jan;30(1):36–9. PMID 23952181. Inadequate follow up time23952181
Desideri G, Kwik-Uribe C, Grassi D, . Benefits in cognitive function, blood pressure, and insulin resistance through cocoa flavanol consumption in elderly subjects with mild cognitive impairment: the Cocoa, Cognition, and Aging (CoCoA) study. Hypertension. 2012 Sep;60(3):794–801. PMID 22892813. Inadequate follow up time22892813
Desikan RS, Thompson WK, Holland D, . Heart fatty acid binding protein and Abeta-associated Alzheimer’s neurodegeneration. Molecular Neurodegeneration. 2013;8:39. PMID 24088526. Cohort study with inadequate sample size24088526
Devanand DP. Donepezil treatment of older adults with cognitive impairment and depression (DOTCODE study): clinical rationale and design. Contemporary clinical trials. 2014 01 Mar;37(2):200–8. PMID 24315979. Ineligible population24315979
Devore EE, Grodstein F, van Rooij FJ, . Dietary intake of fish and omega-3 fatty acids in relation to long-term dementia risk. American Journal of Clinical Nutrition. 2009 Jul;90(1):170–6. PMID 19474131. Not cognitive decline prevention intervention19474131
Devore EE, Grodstein F, van Rooij FJ, . Dietary antioxidants and long-term risk of dementia. Archives of Neurology. 2010 Jul;67(7):819–25. PMID 20625087. Not cognitive decline prevention intervention20625087
Devore EE, Kang JH, Breteler MM, . Dietary intakes of berries and flavonoids in relation to cognitive decline. Annals of Neurology. 2012 Jul;72(1):135–43. PMID 22535616. Not cognitive decline prevention intervention22535616
Di Stefano F, Epelbaum S, Coley N, . Prediction of Alzheimer’s Disease Dementia: Data from the GuidAge Prevention Trial. Journal of Alzheimer’s Disease. 2015 01 Oct;48(3):793–804. PMID 2015438468. Ineligible study design
Diamond K, Mowszowski L, Cockayne N, . Randomized controlled trial of a healthy brain ageing cognitive training program: effects on memory, mood, and sleep. Journal of Alzheimer’s Disease. 2015;44(4):1181–91. PMID 25408218. Ineligible population25408218
Diener HC. [No immediate dementia prevention from antihypertensive therapy]. 2009. http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/346/CN-00757346/frame.html. Accessed on 1 32. Not available in English
Diniz BS, Pinto JA, Jr., Gonzaga ML, . To treat or not to treat? A meta-analysis of the use of cholinesterase inhibitors in mild cognitive impairment for delaying progression to Alzheimer’s disease. European Archives of Psychiatry & Clinical Neuroscience. 2009 Jun;259(4):248–56. PMID 19224111. Ineligible study design19224111
Dodel R, Rominger A, Bartenstein P, . Intravenous immunoglobulin for treatment of mild-to-moderate Alzheimer’s disease: a phase 2, randomised, double-blind, placebo-controlled, dose-finding trial. Lancet Neurology. 2013 Mar;12(3):233–43. PMID 23375965. Ineligible population23375965
Doi T, Makizako H, Shimada H, . Effects of multicomponent exercise on spatial-temporal gait parameters among the elderly with amnestic mild cognitive impairment (aMCI): preliminary results from a randomized controlled trial (RCT). Archives of Gerontology & Geriatrics. 2013 Jan–Feb;56(1):104–8. PMID 23063111. No relevant outcomes reported23063111
Dong ZH, Zhang CY, Pu BH. [Effects of ginkgo biloba tablet in treating mild cognitive impairment]. [Chinese]. Zhongguo Zhong xi yi jie he za zhi Zhongguo Zhongxiyi jiehe zazhi = Chinese journal of integrated traditional and Western medicine / Zhongguo Zhong xi yi jie he xue hui, Zhongguo Zhong yi yan jiu yuan zhu ban. 2012 Sep;32(9):1208–11. PMID 23185760. Not available in English23185760
D’Onofrio G, Sancarlo D, Addante F, . A pilot randomized controlled trial evaluating an integrated treatment of rivastigmine transdermal patch and cognitive stimulation in patients with Alzheimer’s disease. International Journal of Geriatric Psychiatry. 2015 01 Sep;30(9):965–75. PMID 2015662652. Ineligible population25504466
Doody RS, Ferris S, Salloway S, . Safety and tolerability of donepezil in mild cognitive impairment: open-label extension study. American Journal of Alzheimer’s Disease & Other Dementias. 2010 Mar;25(2):155–9. PMID 19949165. Ineligible population19949165
Doody RS, Geldmacher DS, Farlow MR, . Efficacy and safety of donepezil 23 mg versus donepezil 10 mg for moderate-to-severe Alzheimer’s disease: a subgroup analysis in patients already taking or not taking concomitant memantine. Dementia & Geriatric Cognitive Disorders. 2012;33(2–3):164–73. PMID 22572767. Ineligible population22572767
Doody RS, Thomas RG, Farlow M, . Phase 3 trials of solanezumab for mild-to-moderate Alzheimer’s disease. New England Journal of Medicine. 2014 Jan 23;370(4):311–21. PMID 24450890. Ineligible population24450890
Dotson VM, Beydoun MA, Zonderman AB. Recurrent depressive symptoms and the incidence of dementia and mild cognitive impairment. Neurology. 2010 Jul 6;75(1):27–34. PMID 20603482. Not cognitive decline prevention intervention20603482
Drake C, Gumenyuk V, Roth T, . Effects of armodafinil on simulated driving and alertness in shift work disorder. Sleep. 2014 Dec;37(12):1987–94. PMID 25325498. No relevant outcomes reported25325498
Dretsch MN, Johnston D, Bradley RS, . Effects of omega-3 fatty acid supplementation on neurocognitive functioning and mood in deployed U.S. soldiers: a pilot study. Military Medicine. 2014 Apr;179(4):396–403. PMID 24690964. Ineligible population24690964
Drks. ELITE study - Nutrition, lifestyle and individual information for the prevention of stroke, dementia and heart attack. 2014. http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/895/CN-01066895/frame.html. Ineligible study design
Drumond Marra HL, Myczkowski ML, Maia Memoria C, . Transcranial Magnetic Stimulation to Address Mild Cognitive Impairment in the Elderly: A Randomized Controlled Study. Behavioural Neurology. 2015;2015(287843)PMID 2015173487. Inadequate follow up time
Dunbar GC, Kuchibhatla RV, Lee G. A randomized double-blind study comparing 25 and 50 mg TC-1734 (AZD3480) with placebo, in older subjects with age-associated memory impairment. Journal of Psychopharmacology. 2011 August;25(8):1020–9. PMID 2011470672. Ineligible population20542923
Duron E, Rigaud AS, Dubail D, . Effects of antihypertensive therapy on cognitive decline in Alzheimer’s disease. American Journal of Hypertension. 2009 Sep;22(9):1020–4. PMID 19590498. Ineligible population19590498
Dustman RE, Ruhling RO, Russell EM, . Aerobic exercise training and improved neuropsychological function of older individuals. Neurobiology of Aging. 1984;5(1):35–42. PMID 6738784. Inadequate follow up time6738784
Dysken MW, Sano M, Asthana S, . Effect of vitamin E and memantine on functional decline in Alzheimer disease: The TEAM-AD VA cooperative randomized trial. JAMA - Journal of the American Medical Association. 2014;311(1):33–44. PMID 2014045856. Ineligible population24381967
Dysken MW, Sano M, Asthana S, . Effect of vitamin E and memantine on functional decline in Alzheimer disease: the TEAM-AD VA cooperative randomized trial.[Erratum appears in JAMA. 2014 Mar 19;311(11):1161]. JAMA. 2014 Jan 1;311(1):33–44. PMID 24381967. Ineligible population24381967
Eckroth-Bucher M, Siberski J. Preserving cognition through an integrated cognitive stimulation and training program. American Journal of Alzheimer’s Disease & Other Dementias. 2009 Jun–Jul;24(3):234–45. PMID 19346501. Ineligible population19346501
Edwards J, Wadley V, Myers R, . Transfer of a speed of processing intervention to near and far cognitive functions. Gerontology. 2002 Sep–Oct;48(5):329–40. PMID 12169801. Ineligible population12169801
Edwards JD, Delahunt PB, Mahncke HW. Cognitive speed of processing training delays driving cessation. Journals of Gerontology Series A-Biological Sciences & Medical Sciences. 2009 Dec;64(12):1262–7. PMID 19726665. No relevant outcomes reported19726665
Edwards JD, Myers C, Ross LA, . The longitudinal impact of cognitive speed of processing training on driving mobility. Gerontologist. 2009 Aug;49(4):485–94. PMID 19491362. No relevant outcomes reported19491362
Edwards JD, Ruva CL, O’Brien JL, . An examination of mediators of the transfer of cognitive speed of processing training to everyday functional performance. Psychology & Aging. 2013 Jun;28(2):314–21. PMID 23066808. Inadequate follow up time23066808
Edwards JD, Valdes EG, Peronto C, . The Efficacy of InSight Cognitive Training to Improve Useful Field of View Performance: A Brief Report. Journals of Gerontology Series B-Psychological Sciences & Social Sciences. 2015 May;70(3):417–22. PMID 24211819. Inadequate follow up time24211819
Edwards JD, Wadley VG, Vance DE, . The impact of speed of processing training on cognitive and everyday performance. Aging & Mental Health. 2005 May;9(3):262–71. PMID 16019280. Inadequate follow up time16019280
Elias MF, Goodell AL. Diet and exercise: blood pressure and cognition: to protect and serve. Hypertension. 2010 Jun;55(6):1296–8. PMID 20385968. Inadequate follow up time20385968
Ellis KA, Bush AI, Darby D, . The Australian Imaging, Biomarkers and Lifestyle (AIBL) study of aging: methodology and baseline characteristics of 1112 individuals recruited for a longitudinal study of Alzheimer’s disease. International Psychogeriatrics. 2009 Aug;21(4):672–87. PMID 19470201. Ineligible study design19470201
Ellis KA, Rowe CC, Villemagne VL, . Addressing population aging and Alzheimer’s disease through the Australian imaging biomarkers and lifestyle study: collaboration with the Alzheimer’s Disease Neuroimaging Initiative. Alzheimer’s & Dementia. 2010 May;6(3):291–6. PMID 20451879. Ineligible study design20451879
Ellis KA, Szoeke C, Bush AI, . Rates of diagnostic transition and cognitive change at 18-month follow-up among 1,112 participants in the Australian Imaging, Biomarkers and Lifestyle Flagship Study of Ageing (AIBL). International Psychogeriatrics. 2014 Apr;26(4):543–54. PMID 24252258. Ineligible study design24252258
Elmstahl S, Widerstrom E. Orthostatic intolerance predicts mild cognitive impairment: incidence of mild cognitive impairment and dementia from the Swedish general population cohort Good Aging in Skane. Clinical Interventions In Aging. 2014;9:1993–2002. PMID 25429211. Not cognitive decline prevention intervention25429211
Engedal K, Davis B, Richarz U, . Two galantamine titration regimens in patients switched from donepezil. Acta Neurologica Scandinavica. 2012 Jul;126(1):37–44. PMID 21992111. Ineligible population21992111
Erickson KI, Colcombe SJ, Wadhwa R, . Training-induced plasticity in older adults: effects of training on hemispheric asymmetry. Neurobiology of Aging. 2007 Feb;28(2):272–83. PMID 16480789. Inadequate follow up time16480789
Erickson KI, Raji CA, Lopez OL, . Physical activity predicts gray matter volume in late adulthood: the Cardiovascular Health Study. Neurology. 2010 Oct 19;75(16):1415–22. PMID 20944075. Ineligible study design20944075
Esin E, Ergen A, Cankurtaran M, . Influence of antimuscarinic therapy on cognitive functions and quality of life in geriatric patients treated for overactive bladder. Aging & Mental Health. 2015;19(3):217–23. PMID 25555041. Ineligible population25555041
Eskelinen MH, Ngandu T, Tuomilehto J, . Midlife coffee and tea drinking and the risk of late-life dementia: a population-based CAIDE study. Journal of Alzheimer’s Disease. 2009;16(1):85–91. PMID 19158424. Not cognitive decline prevention intervention19158424
Espeland MA, Rapp SR, Bray GA, . Long-term impact of behavioral weight loss intervention on cognitive function. Journals of Gerontology Series A-Biological Sciences & Medical Sciences. 2014 Sep;69(9):1101–8. PMID 24619151. Ineligible population24619151
Espeland MA, Tindle HA, Bushnell CA, . Brain volumes, cognitive impairment, and conjugated equine estrogens. Journals of Gerontology Series A-Biological Sciences & Medical Sciences. 2009 Dec;64(12):1243–50. PMID 19729392. Not cognitive decline prevention intervention19729392
Estruch R, Ros E, Salas-Salvado J, . Primary prevention of cardiovascular disease with a Mediterranean diet.[Erratum appears in N Engl J Med. 2014 Feb 27;370(9):886]. New England Journal of Medicine. 2013 Apr 4;368(14):1279–90. PMID 23432189. No relevant outcomes reported23432189
Etgen T, Sander D, Chonchol M, . Chronic kidney disease is associated with incident cognitive impairment in the elderly: The INVADE study. Nephrology Dialysis Transplantation. 2009 October;24(10):3144–50. PMID 2009517458. Not cognitive decline prevention intervention
Etgen T, Sander D, Huntgeburth U, . Physical activity and incident cognitive impairment in elderly persons: the INVADE study. Archives of Internal Medicine. 2010 Jan 25;170(2):186–93. PMID 20101014. Not cognitive decline prevention intervention20101014
Euser SM, Sattar N, Witteman JC, . A prospective analysis of elevated fasting glucose levels and cognitive function in older people: results from PROSPER and the Rotterdam Study. Diabetes. 2010 Jul;59(7):1601–7. PMID 20393152. Ineligible population20393152
Fairchild JK, Scogin FR. Training to Enhance Adult Memory (TEAM): an investigation of the effectiveness of a memory training program with older adults. Aging & Mental Health. 2010 Apr;14(3):364–73. PMID 20425656. Inadequate follow up time20425656
Fallah N, Hsu CL, Bolandzadeh N, . A multistate model of cognitive dynamics in relation to resistance training: the contribution of baseline function. Annals of Epidemiology. 2013 Aug;23(8):463–8. PMID 23830936. No relevant outcomes reported23830936
Fan HG, Park A, Xu W, . The influence of erythropoietin on cognitive function in women following chemotherapy for breast cancer. Psycho-Oncology. 2009 Feb;18(2):156–61. PMID 18561284. Ineligible population18561284
Fan YL, Wan JQ, Zhou ZW, . Neurocognitive improvement after carotid artery stenting in patients with chronic internal carotid artery occlusion: a prospective, controlled, single-center study. Vascular & Endovascular Surgery. 2014 May;48(4):305–10. PMID 24643000. Ineligible population24643000
Farokhnia M, Shafiee Sabet M, Iranpour N, . Comparing the efficacy and safety of Crocus sativus L. with memantine in patients with moderate to severe Alzheimer’s disease: a double-blind randomized clinical trial. Human Psychopharmacology. 2014 Jul;29(4):351–9. PMID 25163440. Ineligible population25163440
Feart C, Samieri C, Rondeau V, . Adherence to a Mediterranean diet, cognitive decline, and risk of dementia.[Erratum appears in JAMA. 2009 Dec 9;302(22):2436]. JAMA. 2009 Aug 12;302(6):638–48. PMID 19671905. Ineligible population19671905
Feldman HH, Doody RS, Kivipelto M, . Randomized controlled trial of atorvastatin in mild to moderate Alzheimer disease: LEADe. Neurology. 2010 March;74(12):956–64. PMID 2010189030. Ineligible population20200346
Felix HC, Adams B, Fausett JK, . Calculating reach of evidence-based weight loss and memory improvement interventions among older adults attending Arkansas senior centers, 2008–2011. Preventing Chronic Disease. 2012;9:E63. PMID 22360874. No relevant outcomes reported22360874
Feliziani FT, Polidori MC, De Rango P, . Cognitive performance in elderly patients undergoing carotid endarterectomy or carotid artery stenting: a twelve-month follow-up study. Cerebrovascular Diseases. 2010 Aug;30(3):244–51. PMID 20664257. Ineligible population20664257
Feng L, Fam J, Rawtaer I, . Mindful awareness practice for the prevention of dementia: A randomised controlled trial [Journal: Conference Abstract]. 2014. http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/105/CN-01053105/frame.html. Accessed on 10 suppl. 1 43. Ineligible study design
Feng L, Li J, Ng TP, . Tea drinking and cognitive function in oldest-old Chinese. Journal of Nutrition, Health & Aging. 2012;16(9):754–8. PMID 23131816. Ineligible population23131816
Ferris S, Lane R, Sfikas N, . Effects of gender on response to treatment with rivastigmine in mild cognitive impairment: A post hoc statistical modeling approach. Gender Medicine. 2009 Jul;6(2):345–55. PMID 19682661. Ineligible study design19682661
Ferris S, Nordberg A, Soininen H, . Progression from mild cognitive impairment to Alzheimer’s disease: effects of sex, butyrylcholinesterase genotype, and rivastigmine treatment. Pharmacogenetics and Genomics. 2009 Aug;19(8):635–46. PMID 19617863. Ineligible study design19617863
Fiala M, Halder RC, Sagong B, . omega-3 Supplementation increases amyloid-beta phagocytosis and resolvin D1 in patients with minor cognitive impairment. FASEB Journal. 2015 Jul;29(7):2681–9. PMID 25805829. Ineligible population25805829
Fields C, Drye L, Vaidya V, . Celecoxib or naproxen treatment does not benefit depressive symptoms in persons age 70 and older: findings from a randomized controlled trial. American Journal of Geriatric Psychiatry. 2012 Jun;20(6):505–13. PMID 21775876. No relevant outcomes reported21775876
Finn M, McDonald S. Computerised cognitive training for older persons with mild cognitive impairment: A pilot study using a randomised controlled trial design. Brain Impairment. 2011 December;12(3):187–99. PMID 2012003537. Inadequate follow up time
Fiocco AJ, Scarcello S, Marzolini S, . The effects of an exercise and lifestyle intervention program on cardiovascular, metabolic factors and cognitive performance in middle-aged adults with type II diabetes: a pilot study. Canadian Journal of Diabetes. 2013 Aug;37(4):214–9. PMID 24070883. Ineligible study design24070883
Ford AH, Flicker L, Alfonso H, . Vitamins B(12), B(6), and folic acid for cognition in older men.[Erratum appears in Neurology. 2011 Aug 23;77((8):804 Note: Dosage error in published abstract; MEDLINE/PubMed abstract corrected; Dosage error in article text]. Neurology. 2010 Oct 26;75(17):1540–7. PMID 20861451. Ineligible population20861451
Forster S, Buschert VC, Buchholz HG, . Effects of a 6-month cognitive intervention program on brain metabolism in amnestic mild cognitive impairment and mild Alzheimer’s disease. Journal of Alzheimer’s Disease. 2011;25(4):695–706. PMID 21498904. Ineligible population21498904
Forti P, Olivelli V, Rietti E, . Serum thyroid-stimulating hormone as a predictor of cognitive impairment in an elderly cohort. Gerontology. 2012;58(1):41–9. PMID 21430364. Not cognitive decline prevention intervention21430364
Foubert-Samier A, Le Goff M, Helmer C, . Change in leisure and social activities and risk of dementia in elderly cohort. Journal of Nutrition, Health & Aging. 2014 Dec;18(10):876–82. PMID 25470802. Not cognitive decline prevention intervention25470802
Fowler SB. Cognition training interventions for healthy older people and older people with mild cognitive impairment. Clinical Nurse Specialist. 2011 Jul–Aug;25(4):178–9. PMID 21654372. Ineligible study design21654372
Fox C, Richardson K, Maidment ID, . Anticholinergic medication use and cognitive impairment in the older population: the medical research council cognitive function and ageing study. Journal of the American Geriatrics Society. 2011 Aug;59(8):1477–83. PMID 21707557. Not cognitive decline prevention intervention21707557
Fox M, Berzuini C, Knapp LA. Cumulative estrogen exposure, number of menstrual cycles, and Alzheimer’s risk in a cohort of British women. Psychoneuroendocrinology. 2013 Dec;38(12):2973–82. PMID 24064221. Ineligible population24064221
Frolich L, Ashwood T, Nilsson J, . Effects of AZD3480 on cognition in patients with mild-to-moderate Alzheimer’s disease: a phase IIb dose-finding study. Journal of Alzheimer’s Disease. 2011;24(2):363–74. PMID 21258153. Inadequate follow up time21258153
Gaitan A, Garolera M, Cerulla N, . Efficacy of an adjunctive computer-based cognitive training program in amnestic mild cognitive impairment and Alzheimer’s disease: a single-blind, randomized clinical trial. International Journal of Geriatric Psychiatry. 2013 Jan;28(1):91–9. PMID 22473855. Ineligible population22473855
Galasko DR, Peskind E, Clark CM, . Antioxidants for Alzheimer disease: a randomized clinical trial with cerebrospinal fluid biomarker measures. Archives of Neurology. 2012 Jul;69(7):836–41. PMID 22431837. Ineligible population22431837
Ganio MS, Armstrong LE, Casa DJ, . Mild dehydration impairs cognitive performance and mood of men. British Journal of Nutrition. 2011 Nov;106(10):1535–43. PMID 21736786. No relevant outcomes reported21736786
Gao Q, Niti M, Feng L, . Omega-3 polyunsaturated fatty acid supplements and cognitive decline: Singapore Longitudinal Aging Studies. Journal of Nutrition, Health & Aging. 2011 Jan;15(1):32–5. PMID 21267519. Not cognitive decline prevention intervention21267519
Gao S, Nguyen JT, Hendrie HC, . Accelerated weight loss and incident dementia in an elderly African-American cohort. Journal of the American Geriatrics Society. 2011 Jan;59(1):18–25. PMID 21054328. Not cognitive decline prevention intervention21054328
Garand L, Rinaldo DE, Alberth MM, . Effects of problem solving therapy on mental health outcomes in family caregivers of persons with a new diagnosis of mild cognitive impairment or early dementia: a randomized controlled trial. American Journal of Geriatric Psychiatry. 2014 Aug;22(8):771–81. PMID 24119856. Ineligible population24119856
Gates NJ, Valenzuela M, Sachdev PS, . Study of Mental Activity and Regular Training (SMART) in at risk individuals: a randomised double blind, sham controlled, longitudinal trial. BMC Geriatrics. 2011;11:19. PMID 21510896. Ineligible study design21510896
Gaudig M, Richarz U, Han J, . Effects of galantamine in Alzheimer’s disease: double-blind withdrawal studies evaluating sustained versus interrupted treatment. Current Alzheimer Research. 2011 Nov;8(7):771–80. PMID 21707533. Ineligible population21707533
Gavrilova SI, Fedorova IB, Gantman, . [Ceraxon (citicoline) in the treatment of the mild cognitive impairment syndrome]. [Russian]. Zhurnal nevrologii i psikhiatrii imeni S.S. 2011;Korsakova / Ministerstvo zdravookhraneniia i meditsinskoi promyshlennosti Rossiiskoi Federatsii, Vserossiiskoe obshchestvo nevrologov [i] Vserossiiskoe obshchestvo psikhiatrov. 111(12):16–20. PMID 22433803. Not available in English22433803
Gavrilova SI, Kolykhalov IV, Fedorova Ya B, . Possibilities of preventive treatment of Alzheimer’s disease: Results of the 3-year open prospective comparative study on efficacy and safety of the course therapy with cerebrolysin and cavinton in elderly patients with the syndrome of mild cognitive impairment. [Russian]. Zhurnal Nevrologii i Psihiatrii imeni S.S. 2010;Korsakova. 110(1):62–9. PMID 2010707327. Not available in English
Geda YE, Roberts RO, Knopman DS, . Physical exercise, aging, and mild cognitive impairment: a population-based study. Archives of Neurology. 2010 Jan;67(1):80–6. PMID 20065133. Not cognitive decline prevention intervention20065133
Geda YE, Silber TC, Roberts RO, . Computer activities, physical exercise, aging, and mild cognitive impairment: a population-based study. Mayo Clinic Proceedings. 2012 May;87(5):437–42. PMID 22560523. Not cognitive decline prevention intervention22560523
Gelber RP, Petrovitch H, Masaki KH, . Lifestyle and the risk of dementia in Japanese-american men. Journal of the American Geriatrics Society. 2012 Jan;60(1):118–23. PMID 22211390. Ineligible study design22211390
Gelber RP, Ross GW, Petrovitch H, . Antihypertensive medication use and risk of cognitive impairment: the Honolulu-Asia Aging Study. Neurology. 2013 Sep 3;81(10):888–95. PMID 23911753. Ineligible population23911753
Gengo F, Cwudzinski D, Kinkel P, . Effects of treatment with lovastatin and pravastatin on daytime cognitive performance. Clinical Cardiology. 1995 Apr;18(4):209–14. PMID 7788948. Inadequate follow up time7788948
Genon S, Collette F, Moulin CJ, . Verbal learning in Alzheimer’s disease and mild cognitive impairment: fine-grained acquisition and short-delay consolidation performance and neural correlates. Neurobiology of Aging. 2013 Feb;34(2):361–73. PMID 22592018. Ineligible population22592018
Germano da Paz O, Guillaumon AT, Lopes TM, . Carotid stenting versus endarterectomy cognitive outcomes. Annals of Vascular Surgery. 2014 May;28(4):893–900. PMID 24361382. Ineligible population24361382
Gharacholou SM, Reid KJ, Arnold SV, . Cognitive impairment and outcomes in older adult survivors of acute myocardial infarction: findings from the translational research investigating underlying disparities in acute myocardial infarction patients’ health status registry. American Heart Journal. 2011 Nov;162(5):860–9.e1. PMID 22093202. Ineligible population22093202
Giannantoni A, Cagini R, Del Zingaro M, . Botulinum A toxin intravesical injections for painful bladder syndrome: impact upon pain, psychological functioning and Quality of Life. Current Drug Delivery. 2010 Dec;7(5):442–6. PMID 20950262. Ineligible study design20950262
Gilbertson R, Prather R, Nixon SJ. Acute alcohol administration and placebo effectiveness in older moderate drinkers: influences on cognitive performance. Journal of Studies on Alcohol & Drugs. 2010 May;71(3):345–50. PMID 20409427. Inadequate follow up time20409427
Gildengers AG, Butters MA, Albert SM, . Design and Implementation of an Intervention Development Study: Retaining Cognition while Avoiding Late-Life Depression (ReCALL). American Journal of Geriatric Psychiatry. 2016 01 Jun;24(6):444–54. PMID 610534434. No relevant outcomes reported27066730
Glasser SP, Wadley V, Judd S, . The association of statin use and statin type and cognitive performance: analysis of the reasons for geographic and racial differences in stroke (REGARDS) study. Clinical Cardiology. 2010 May;33(5):280–8. PMID 20513066. Ineligible study design20513066
Godin O, Tzourio C, Maillard P, . Antihypertensive treatment and change in blood pressure are associated with the progression of white matter lesion volumes: the Three-City (3C)-Dijon Magnetic Resonance Imaging Study. Circulation. 2011 Jan 25;123(3):266–73. PMID 21220733. Not cognitive decline prevention intervention21220733
Goh KL, Bhaskaran K, Minassian C, . Angiotensin receptor blockers and risk of dementia: Cohort study in UK Clinical Practice Research Datalink. British Journal of Clinical Pharmacology. 2015 01 Feb;79(2):337–50. PMID 2015433482. Not cognitive decline prevention intervention25223602
Gold M, Alderton C, Zvartau-Hind M, . Rosiglitazone monotherapy in mild-to-moderate Alzheimer’s disease: results from a randomized, double-blind, placebo-controlled phase III study. Dementia & Geriatric Cognitive Disorders. 2010;30(2):131–46. PMID 20733306. Ineligible population20733306
Gomm W, Von Holt K, Thome F, . Association of proton pump inhibitors with risk of dementia: A pharmacoepidemiological claims data analysis. JAMA Neurology. 2016 April;73(4):410–6. PMID 610001802. Not cognitive decline prevention intervention26882076
Gonzalez-Palau F, Franco M, Bamidis P, . The effects of a computer-based cognitive and physical training program in a healthy and mildly cognitive impaired aging sample. Aging & Mental Health. 2014 Sep;18(7):838–46. PMID 24697325. Inadequate follow up time24697325
Gooding AL, Choi J, Fiszdon JM, . Comparing three methods of computerised cognitive training for older adults with subclinical cognitive decline. Neuropsychological rehabilitation. 2015:1–12. Inadequate follow up time
Gooding AL, Choi J, Fiszdon JM, . Comparing three methods of computerised cognitive training for older adults with subclinical cognitive decline. Neuropsychological Rehabilitation. 2016 Sep;26(5–6):810–21. PMID 2016-34409-008. Inadequate follow up time26674122
Gottesman RF, Schneider AL, Albert M, . Midlife hypertension and 20-year cognitive change: the atherosclerosis risk in communities neurocognitive study. JAMA Neurology. 2014 Oct;71(10):1218–27. PMID 25090106. Not cognitive decline prevention intervention25090106
Goveas JS, Hogan PE, Kotchen JM, . Depressive symptoms, antidepressant use, and future cognitive health in postmenopausal women: the Women’s Health Initiative Memory Study. International Psychogeriatrics. 2012 Aug;24(8):1252–64. PMID 22301077. Ineligible population22301077
Graessel E, Stemmer R, Eichenseer B, . Non-pharmacological, multicomponent group therapy in patients with degenerative dementia: a 12-month randomzied, controlled trial. BMC Medicine. 2011 01 Dec;9(129)PMID 2012024517. Ineligible population
Grande G, Vanacore N, Maggiore L, . Physical activity reduces the risk of dementia in mild cognitive impairment subjects: a cohort study. Journal of Alzheimer’s Disease. 2014;39(4):833–9. PMID 24296815. Not cognitive decline prevention intervention24296815
Green RC, Schneider LS, Amato DA, . Effect of tarenflurbil on cognitive decline and activities of daily living in patients with mild Alzheimer disease: a randomized controlled trial. JAMA. 2009 Dec 16;302(23):2557–64. PMID 20009055. Ineligible population20009055
Greenaway MC, Duncan NL, Smith GE. The memory support system for mild cognitive impairment: randomized trial of a cognitive rehabilitation intervention. International Journal of Geriatric Psychiatry. 2013 Apr;28(4):402–9. PMID 22678947. Not cognitive decline prevention intervention22678947
Grossheinrich N, Rau A, Pogarell O, . Theta burst stimulation of the prefrontal cortex: safety and impact on cognition, mood, and resting electroencephalogram. Biological Psychiatry. 2009 May 1;65(9):778–84. PMID 19070834. Inadequate follow up time19070834
Group AI. Study design of ASPirin in Reducing Events in the Elderly (ASPREE): a randomized, controlled trial. Contemporary Clinical Trials. 2013 Nov;36(2):555–64. PMID 24113028. Ineligible study design24113028
Grove RA, Harrington CM, Mahler A, . A randomized, double-blind, placebo-controlled, 16-week study of the H3 receptor antagonist, GSK239512 as a monotherapy in subjects with mild-to-moderate Alzheimer’s disease. Current Alzheimer Research. 2014 Jan;11(1):47–58. PMID 24359500. Inadequate follow up time24359500
Gu Y, Luchsinger JA, Stern Y, . Mediterranean diet, inflammatory and metabolic biomarkers, and risk of Alzheimer’s disease. Journal of Alzheimer’s Disease. 2010;22(2):483–92. PMID 20847399. Not cognitive decline prevention intervention20847399
Gu Y, Nieves JW, Stern Y, . Food combination and Alzheimer disease risk: a protective diet. Archives of Neurology. 2010 Jun;67(6):699–706. PMID 20385883. Ineligible population20385883
Guekht AB, Moessler H, Novak PH, . Cerebrolysin in vascular dementia: improvement of clinical outcome in a randomized, double-blind, placebo-controlled multicenter trial. Journal of Stroke & Cerebrovascular Diseases. 2011 Jul–Aug;20(4):310–8. PMID 20656516. Ineligible population20656516
Guerriero F, Botarelli E, Mele G, . An innovative intervention for the treatment of cognitive impairment-Emisymmetric bilateral stimulation improves cognitive functions in Alzheimer’s disease and mild cognitive impairment: An open-label study. Neuropsychiatric Disease and Treatment. 2015 Sep;11:2391–404. PMID 2015-45683-001. Inadequate follow up time26425094
Guo M, Mi J, Jiang QM, . Metformin may produce antidepressant effects through improvement of cognitive function among depressed patients with diabetes mellitus. Clinical & Experimental Pharmacology & Physiology. 2014 Sep;41(9):650–6. PMID 24862430. Ineligible population24862430
Guo RZ, Zhou WQ, Luo ZG. [Effect of modified huanglian wendan decoction in treating senile patients with mild cognitive impairment of turbid-phlegm blocking orifice syndrome]. [Chinese]. Zhongguo Zhong xi yi jie he za zhi Zhongguo Zhongxiyi jiehe zazhi = Chinese journal of integrated traditional and Western medicine / Zhongguo Zhong xi yi jie he xue hui, Zhongguo Zhong yi yan jiu yuan zhu ban. 2010 Jan;30(1):33–6. PMID 20353029. Ineligible population20353029
Gupta VB, Wilson AC, Burnham S, . Follow-up plasma apolipoprotein e levels in the Australian Imaging, Biomarkers and Lifestyle Flagship Study of Ageing (AIBL) cohort. Alzheimer’s Research and Therapy. 2015 20 Feb;7 (1) (no pagination)(16)PMID 2015908818. Not cognitive decline prevention intervention
Gustafson DR, Backman K, Lissner L, . Leptin and dementia over 32 years-The Prospective Population Study of Women. Alzheimer’s & Dementia. 2012 Jul;8(4):272–7. PMID 22748937. No relevant outcomes reported22748937
Gustavsson A, Jonsson L, Parmler J, . Disease progression and costs of care in Alzheimer’s disease patients treated with donepezil: a longitudinal naturalistic cohort. European Journal of Health Economics. 2012 Oct;13(5):561–8. PMID 21822729. Ineligible study design21822729
Guvenal T, Durna A, Erden O, . Effects of different postmenopausal hormone therapy regimens on cerebral blood flow and cognitive functions. Advances in Therapy. 2009 Aug;26(8):805–11. PMID 19672567. No relevant outcomes reported19672567
Haag MD, Hofman A, Koudstaal PJ, . Duration of antihypertensive drug use and risk of dementia: A prospective cohort study. Neurology. 2009 May 19;72(20):1727–34. PMID 19228584. Not cognitive decline prevention intervention19228584
Haag MDM, Hofman A, Koudstaal PJ, . Statins are associated with a reduced risk of Alzheimer disease regardless of lipophilicity. The Rotterdam Study. Journal of Neurology, Neurosurgery and Psychiatry. 2009 January;80(1):13–7. PMID 2009031438. Not cognitive decline prevention intervention
Hackney ME, Byers C, Butler G, . Adapted Tango Improves Mobility, Motor-Cognitive Function, and Gait but Not Cognition in Older Adults in Independent Living. Journal of the American Geriatrics Society. 2015 Oct;63(10):2105–13. PMID 26456371. Inadequate follow up time26456371
Haenisch B, von Holt K, Wiese B, . Risk of dementia in elderly patients with the use of proton pump inhibitors. European Archives of Psychiatry and Clinical Neuroscience. 2015 24 Oct;265(5):419–28. PMID 2014850429. Not cognitive decline prevention intervention25341874
Hagger-Johnson G, Sabia S, Brunner EJ, . Combined impact of smoking and heavy alcohol use on cognitive decline in early old age: Whitehall II prospective cohort study. British Journal of Psychiatry. 2013 Aug;203(2):120–5. PMID 23846998. Not cognitive decline prevention intervention23846998
Haig GM, Pritchett Y, Meier A, . A randomized study of H3 antagonist ABT-288 in mild-to-moderate Alzheimer’s dementia. Journal of Alzheimer’s Disease. 2014;42(3):959–71. PMID 25024314. Ineligible population25024314
Haimov I, Shatil E. Cognitive training improves sleep quality and cognitive function among older adults with insomnia. PLoS ONE [Electronic Resource]. 2013;8(4):e61390. PMID 23577218. Inadequate follow up time23577218
Hajjar I, Hart M, Chen YL, . Effect of antihypertensive therapy on cognitive function in early executive cognitive impairment: A double-blind randomized clinical trial. Archives of Internal Medicine. 2012 12 Mar;172(5):442–4. PMID 2012161874. Ineligible study design22412114
Hajjar I, Hart M, Mack W, . Aldosterone, cognitive function, and cerebral hemodynamics in hypertension and antihypertensive therapy. American Journal of Hypertension. 2015 Mar;28(3):319–25. PMID 25213687. Not cognitive decline prevention intervention25213687
Hajjar I, Hart M, Milberg W, . The rationale and design of the antihypertensives and vascular, endothelial, and cognitive function (AVEC) trial in elderly hypertensives with early cognitive impairment: role of the renin angiotensin system inhibition. BMC Geriatrics. 2009;9:48. PMID 19922631. Ineligible study design19922631
Hajjar I, Levey A. Association Between Angiotensin Receptor Blockers and Longitudinal Decline in Tau in Mild Cognitive Impairment. JAMA neurology. 2015 01 Sep;72(9):1069–70. PMID 26368351. Not cognitive decline prevention intervention26368351
Hall CB, Lipton RB, Sliwinski M, . Cognitive activities delay onset of memory decline in persons who develop dementia. Neurology. 2009 Aug 4;73(5):356–61. PMID 19652139. Cohort study with inadequate sample size19652139
Haller S, Montandon ML, Rodriguez C, . Acute caffeine administration effect on brain activation patterns in mild cognitive impairment. Journal of Alzheimer’s Disease. 2014;41(1):101–12. PMID 24577471. Inadequate follow up time24577471
Hampel H, Ewers M, Burger K, . Lithium trial in Alzheimer’s disease: A randomized, single-blind, placebo-controlled, multicenter 10-week study. Journal of Clinical Psychiatry. 2009 June;70(6):922–31. PMID 2009309012. Inadequate follow up time19573486
Hampstead BM, Sathian K, Phillips PA, . Mnemonic strategy training improves memory for object location associations in both healthy elderly and patients with amnestic mild cognitive impairment: a randomized, single-blind study. Neuropsychology. 2012 May;26(3):385–99. PMID 22409311. Inadequate follow up time22409311
Hampstead BM, Stringer AY, Stilla RF, . Mnemonic strategy training partially restores hippocampal activity in patients with mild cognitive impairment. Hippocampus. 2012 Aug;22(8):1652–8. PMID 22368035. Inadequate follow up time22368035
Han JW, Oh K, Yoo S, . Development of the ubiquitous spaced retrieval-based memory advancement and rehabilitation training program. Psychiatry Investigation. 2014 January;11(1):52–8. PMID 2014094656. Ineligible study design24605124
Han YR, Song MS, Lim JY. The effects of a cognitive enhancement group training program for community-dwelling elders. Journal of Korean Academy of Nursing. 2010 Oct;40(5):724–35. PMID 21157174. Not available in English21157174
Hanson AJ, Bayer JL, Baker LD, . Differential effects of meal challenges on cognition, metabolism, and biomarkers for apolipoprotein Ebeta 4 carriers and adults with mild cognitive impairment. Journal of Alzheimer’s Disease. 2015 28 Aug;48(1):205–18. PMID 2015360283. Inadequate follow up time
Hanson AJ, Bayer-Carter JL, Green PS, . Effect of apolipoprotein E genotype and diet on apolipoprotein E lipidation and amyloid peptides: randomized clinical trial. JAMA Neurology. 2013 Aug;70(8):972–80. PMID 23779114. Inadequate follow up time23779114
Hardy JL, Nelson RA, Thomason ME, . Enhancing cognitive abilities with comprehensive training: A large, online, randomized, active-controlled trial. PLoS ONE. 2015 Sep;10(9)PMID 2016-01698-001. Inadequate follow up time
Harper PC, Roe CM. Thyroid medication use and subsequent development of dementia of the Alzheimer type. Journal of Geriatric Psychiatry & Neurology. 2010 Mar;23(1):63–9. PMID 19666883. Cohort study with inadequate sample size19666883
Harrington C, Sawchak S, Chiang C, . Rosiglitazone does not improve cognition or global function when used as adjunctive therapy to AChE inhibitors in mild-to-moderate Alzheimer’s disease: two phase 3 studies. Current Alzheimer Research. 2011 Aug;8(5):592–606. PMID 21592048. Ineligible population21592048
Harris E, Macpherson H, Vitetta L, . Effects of a multivitamin, mineral and herbal supplement on cognition and blood biomarkers in older men: a randomised, placebo-controlled trial. Human Psychopharmacology. 2012 Jul;27(4):370–7. PMID 22711385. Inadequate follow up time22711385
Harrison RW, Ashton CH. Do cholesterol-lowering agents affect brain activity? A comparison of simvastatin, pravastatin, and placebo in healthy volunteers. British Journal of Clinical Pharmacology. 1994 Mar;37(3):231–6. PMID 8198930. Inadequate follow up time8198930
Hasler F, Studerus E, Lindner K, . Investigation of serotonin-1A receptor function in the human psychopharmacology of MDMA. Journal of Psychopharmacology. 2009 Nov;23(8):923–35. PMID 18635693. Inadequate follow up time18635693
Hauer D, Weis F, Campolongo P, . Glucocorticoid-endocannabinoid interaction in cardiac surgical patients: relationship to early cognitive dysfunction and late depression. Reviews in the Neurosciences. 2012;23(5–6):681–90. PMID 23006898. Ineligible population23006898
Helmer C, Stengel B, Metzger M, . Chronic kidney disease, cognitive decline, and incident dementia: The 3C Study. Neurology. 2011 06 Dec;77(23):2043–51. PMID 2011672094. Not cognitive decline prevention intervention22116945
Helmstaedter C, Witt JA. Cognitive outcome of antiepileptic treatment with levetiracetam versus carbamazepine monotherapy: a non-interventional surveillance trial. Epilepsy & Behavior. 2010 May;18(1–2):74–80. PMID 20462801. Ineligible study design20462801
Henderson ST, Vogel JL, Barr LJ, . Study of the ketogenic agent AC-1202 in mild to moderate Alzheimer’s disease: A randomized, double-blind, placebo-controlled, multicenter trial. Nutrition and Metabolism. 2009;6(31)PMID 2009460801. Ineligible population
Hendrie HC, Baiyewu O, Lane KA, . Homocysteine levels and dementia risk in Yoruba and African Americans. International Psychogeriatrics. 2013 Nov;25(11):1859–66. PMID 23899991. Not cognitive decline prevention intervention23899991
Heneka MT, Fink A, Doblhammer G. Effect of pioglitazone medication on the incidence of dementia. Annals of Neurology. 2015 Aug;78(2):284–94. PMID 25974006. Not cognitive decline prevention intervention25974006
Herrschaft H, Nacu A, Likhachev S, . Ginkgo biloba extract EGb 761 in dementia with neuropsychiatric features: a randomised, placebo-controlled trial to confirm the efficacy and safety of a daily dose of 240 mg. Journal of Psychiatric Research. 2012 Jun;46(6):716–23. PMID 22459264. Ineligible population22459264
Hietanen H, Pietila A, Kahonen M, . Ankle blood pressure and dementia: A prospective follow-up study. Blood Pressure Monitoring. 2013 February;18(1):16–20. PMID 2013023251. Not cognitive decline prevention intervention23275314
Hill NL, Kolanowski AM, Fick D, . Personality as a moderator of cognitive stimulation in older adults at high risk for cognitive decline. Research in Gerontological Nursing. 2014 Jul–Aug;7(4):159–70. PMID 24635006. Not cognitive decline prevention intervention24635006
Hinkelmann K, Wingenfeld K, Kuehl LK, . Stimulation of the mineralocorticoid receptor improves memory in young and elderly healthy individuals. Neurobiology of Aging. 2015 Feb;36(2):919–24. PMID 25442112. Inadequate follow up time25442112
Holinski S, Claus B, Alaaraj N, . Cerebroprotective effect of piracetam in patients undergoing open heart surgery. Annals of Thoracic & Cardiovascular Surgery. 2011;17(2):137–42. PMID 21597409. Ineligible population21597409
Holtzman DM. CSF biomarkers for secondary prevention trials: Why markers of amyloid deposition and neurodegeneration are both important. Archives of Neurology. 2012 Jun;69(6):691–2. PMID 2012-16571-001. Ineligible study design22529246
Holzgreve H. [Hypertensive and organ damage. Dementia and cognitive impairment]. MMW Fortschritte der Medizin. 2011 Sep 22;153(38):99–100. PMID 21977804. Not available in English21977804
Homma A, Imai Y, Tago H, . Long-term safety and efficacy of donepezil in patients with severe Alzheimer’s disease: results from a 52-week, open-label, multicenter, extension study in Japan. Dementia & Geriatric Cognitive Disorders. 2009;27(3):232–9. PMID 19246907. Ineligible population19246907
Hoogenhout EM, de Groot RH, van der Elst W, . Effects of a comprehensive educational group intervention in older women with cognitive complaints: a randomized controlled trial. Aging & Mental Health. 2012;16(2):135–44. PMID 21780962. Inadequate follow up time21780962
Hooshmand B, Solomon A, Kareholt I, . Associations between serum homocysteine, holotranscobalamin, folate and cognition in the elderly: a longitudinal study. Journal of Internal Medicine. 2012 Feb;271(2):204–12. PMID 22077644. Not cognitive decline prevention intervention22077644
Hornslien AG, Sandset EC, Bath PM, . Effects of candesartan in acute stroke on cognitive function and quality of life: results from the Scandinavian Candesartan Acute Stroke Trial. Stroke. 2013 Jul;44(7):2022–4. PMID 23660849. Ineligible population23660849
Howard R, McShane R, Lindesay J, . Donepezil and memantine for moderate-to-severe Alzheimer’s disease. New England Journal of Medicine. 2012 Mar 8;366(10):893–903. PMID 22397651. Ineligible population22397651
Hsu CC, Wahlqvist ML, Lee MS, . Incidence of dementia is increased in type 2 diabetes and reduced by the use of sulfonylureas and metformin. Journal of Alzheimer’s Disease. 2011;24(3):485–93. PMID 21297276. Not cognitive decline prevention intervention21297276
Hsu CY, Huang CC, Chan WL, . Angiotensin-receptor blockers and risk of Alzheimer’s disease in hypertension population--a nationwide cohort study. Circulation Journal. 2013;77(2):405–10. PMID 23149416. Not cognitive decline prevention intervention23149416
Hsu CY, Huang CC, Chan WL, . Angiotensin-receptor blockers and risk of alzheimer’s disease in hypertension population - A nationwide cohort study. Circulation Journal. 2013;77(2):405–10. PMID 2013074487. Not cognitive decline prevention intervention23149416
Huang CQ, Dong BR, Zhang YL, . Association of cognitive impairment with smoking, alcohol consumption, tea consumption, and exercise among Chinese nonagenarians/centenarians. Cognitive & Behavioral Neurology. 2009 Sep;22(3):190–6. PMID 19741330. Not cognitive decline prevention intervention19741330
Hughes TF, Becker JT, Lee CW, . Independent and combined effects of cognitive and physical activity on incident MCI. Alzheimer’s and Dementia. 2015 November;11(11):1377–84. PMID 2015949579. Not cognitive decline prevention intervention
Hughes TF, Flatt JD, Fu B, . Engagement in social activities and progression from mild to severe cognitive impairment: the MYHAT study. International Psychogeriatrics. 2013 Apr;25(4):587–95. PMID 23257280. Not cognitive decline prevention intervention23257280
Ihl R, Bachinskaya N, Korczyn AD, . Efficacy and safety of a once-daily formulation of Ginkgo biloba extract EGb 761 in dementia with neuropsychiatric features: a randomized controlled trial. International Journal of Geriatric Psychiatry. 2011 Nov;26(11):1186–94. PMID 21140383. Ineligible population21140383
Ihl R, Tribanek M, Bachinskaya N, . Efficacy and tolerability of a once daily formulation of Ginkgo biloba extract EGb 761 in Alzheimer’s disease and vascular dementia: results from a randomised controlled trial. Pharmacopsychiatry. 2012 Mar;45(2):41–6. PMID 22086747. Ineligible population22086747
Ihle-Hansen H, Thommessen B, Fagerland MW, . Multifactorial vascular risk factor intervention to prevent cognitive impairment after stroke and TIA: a 12-month randomized controlled trial. International Journal of Stroke. 2014 Oct;9(7):932–8. PMID 23205666. Ineligible population23205666
Ikeda M, Mori E, Kosaka K, . Long-term safety and efficacy of donepezil in patients with dementia with Lewy bodies: results from a 52-week, open-label, multicenter extension study. Dementia & Geriatric Cognitive Disorders. 2013;36(3–4):229–41. PMID 23949147. Ineligible population23949147
Ikeda M, Mori E, Matsuo K, . Donepezil for dementia with Lewy bodies: A randomized, placebo-controlled, confirmatory phase III trial. Alzheimer’s Research and Therapy. 2015;7(1)PMID 2015872011. Ineligible population
Ilieva I, Boland J, Farah MJ. Objective and subjective cognitive enhancing effects of mixed amphetamine salts in healthy people. Neuropharmacology. 2013 Jan;64:496–505. PMID 22884611. Inadequate follow up time22884611
Inaba M, White L, Bell C, . White matter lesions on brain magnetic resonance imaging scan and 5-year cognitive decline: The honolulu-asia aging study. Journal of the American Geriatrics Society. 2011 August;59(8):1484–9. PMID 2011457234. Cohort study with inadequate sample size21718274
Irizarry MC, Raman R, Schwarzschild MA, . Plasma urate and progression of mild cognitive impairment. Neurodegenerative Diseases. 2009;6(1–2):23–8. PMID 19066433. Not cognitive decline prevention intervention19066433
Irwin C, Leveritt M, Shum D, . The effects of dehydration, moderate alcohol consumption, and rehydration on cognitive functions. Alcohol. 2013 May;47(3):203–13. PMID 23352231. Inadequate follow up time23352231
Ishihara H, Oka F, Shirao S, . Cognitive outcome differences on the side of carotid artery stenting. Journal of Vascular Surgery. 2013 Jan;57(1):125–30. PMID 23141681. Ineligible population23141681
Iso-Markku P, Waller K, Kujala UM, . Physical activity and dementia: long-term follow-up study of adult twins. Annals of Medicine. 2015 Mar;47(2):81–7. PMID 25613168. Not cognitive decline prevention intervention25613168
Iwasa H, Yoshida Y, Kai I, . Leisure activities and cognitive function in elderly community-dwelling individuals in Japan: a 5-year prospective cohort study. Journal of Psychosomatic Research. 2012 Feb;72(2):159–64. PMID 22281459. Not cognitive decline prevention intervention22281459
Jackson PA, Deary ME, Reay JL, . No effect of 12 weeks’ supplementation with 1 g DHA-rich or EPA-rich fish oil on cognitive function or mood in healthy young adults aged 18–35 years. British Journal of Nutrition. 2012 Apr;107(8):1232–43. PMID 21864417. Inadequate follow up time21864417
Jacobs HI, Riphagen JM, Razat CM, . Transcutaneous vagus nerve stimulation boosts associative memory in older individuals. Neurobiology of Aging. 2015 May;36(5):1860–7. PMID 2015-13241-001. Inadequate follow up time25805212
Jacobs HIL, Riphagen JM, Razat CM, . Transcutaneous vagus nerve stimulation boosts associative memory in older individuals. Neurobiology of Aging. 2015;36(5):1860–7. PMID 2015849982. Inadequate follow up time25805212
Jacobs V, Woller SC, Stevens SM, . Percent time with a supratherapeutic INR in atrial fibrillation patients also using an antiplatelet agent is associated with long-term risk of dementia. Journal of Cardiovascular Electrophysiology. 2015 November;26(11):1180–6. PMID 2015478510. Cohort study with inadequate sample size
Janicki SC, Park N, Cheng R, . Estrogen receptor alpha variants affect age at onset of Alzheimer’s disease in a multiethnic female cohort. Dementia & Geriatric Cognitive Disorders. 2014;38(3–4):200–13. PMID 24732579. Not cognitive decline prevention intervention24732579
Jaremka LM, Derry HM, Bornstein R, . Omega-3 supplementation and loneliness-related memory problems: secondary analyses of a randomized controlled trial. Psychosomatic Medicine. 2014 Oct;76(8):650–8. PMID 25264972. Inadequate follow up time25264972
Jean L, Simard M, Wiederkehr S, . Efficacy of a cognitive training programme for mild cognitive impairment: results of a randomised controlled study. Neuropsychological Rehabilitation. 2010 Jun;20(3):377–405. PMID 20029715. Inadequate follow up time20029715
Jerneren F, Elshorbagy AK, Oulhaj A, . Brain atrophy in cognitively impaired elderly: the importance of long-chain omega-3 fatty acids and B vitamin status in a randomized controlled trial. American Journal of Clinical Nutrition. 2015 Jul;102(1):215–21. PMID 25877495. Ineligible study design25877495
Jiang B, Ding C, Yao G, . Intervention effect of folic acid and vitamin B12 on vascular cognitive impairment complicated with hyperhomocysteinemia. Journal of Medical Biochemistry. 2014 April–June;33(2):169–74. PMID 2014475097. Ineligible population
Jiang D, Chu X, Hu L, . Yizhi Xingnao prescription improves the cognitive function of patients after a transient ischemic attack. Neural Regeneration Research. 2012 February;7(6):434–9. PMID 2012142010. Ineligible population25774185
Jick H, Zornberg GL, Jick SS, . Statins and the risk of dementia.[Erratum appears in Lancet 2001 Feb 17;357(9255):562]. Lancet. 2000 Nov 11;356(9242):1627–31. PMID 11089820. Ineligible study design11089820
Joas E, Backman K, Gustafson D, . Blood pressure trajectories from midlife to late life in relation to dementia in women followed for 37 years. Hypertension. 2012 Apr;59(4):796–801. PMID 22331381. Not cognitive decline prevention intervention22331381
Johansson L, Guo X, Hallstrom T, . Common psychosocial stressors in middle-aged women related to longstanding distress and increased risk of Alzheimer’s disease: A 38-year longitudinal population study. BMJ Open. 2013;3 (9) (no pagination)(e003142)PMID 2013640644. Not cognitive decline prevention intervention
Johnston H, Boutin H, Allan SM. Assessing the contribution of inflammation in models of Alzheimer’s disease. Biochemical Society Transactions. 2011 August;39(4):886–90. PMID 2011415298. Ineligible study design21787318
Kamegaya T, Araki Y, Kigure H, . Twelve-week physical and leisure activity programme improved cognitive function in community-dwelling elderly subjects: a randomized controlled trial. Psychogeriatrics:The Official Journal of the Japanese Psychogeriatric Society. 2014 Mar;14(1):47–54. PMID 24528600. Inadequate follow up time24528600
Kang JH, Grodstein F. Regular use of nonsteroidal anti-inflammatory drugs and cognitive function in aging women. Neurology. 2003 May 27;60(10):1591–7. PMID 12771247. Not cognitive decline prevention intervention12771247
Karr JE, Grindstaff TR, Alexander JE. Omega-3 polyunsaturated fatty acids and cognition in a college-aged population. Experimental & Clinical Psychopharmacology. 2012 Jun;20(3):236–42. PMID 22250656. Inadequate follow up time22250656
Kaschel R. [Ginkgo extract in people with declining mental performance]. Pharmazie in Unserer Zeit. 2009;38(5):432–9. PMID 19711319. Not available in English19711319
Kaschel R. Specific memory effects of Ginkgo biloba extract EGb 761 in middle-aged healthy volunteers. Phytomedicine. 2011 Nov 15;18(14):1202–7. PMID 21802920. Inadequate follow up time21802920
Katon W, Lyles CR, Parker MM, . Association of depression with increased risk of dementia in patients with type 2 diabetes: the Diabetes and Aging Study. Archives of General Psychiatry. 2012 Apr;69(4):410–7. PMID 22147809. Not cognitive decline prevention intervention22147809
Kawashima R. [Prevention of dementia by social activity]. Nippon Rinsho - Japanese Journal of Clinical Medicine. 2011 Dec;69 Suppl 10(Pt 2):212–6. PMID 22755186. Not available in English22755186
Kawashima R. Mental exercises for cognitive function: clinical evidence. Journal of Preventive Medicine & Public Health / Yebang Uihakhoe Chi. 2013 Jan;46 Suppl 1:S22–7. PMID 23412645. Ineligible population23412645
Kay GG, Maruff P, Scholfield D, . Evaluation of cognitive function in healthy older subjects treated with fesoterodine. Postgraduate Medicine. 2012 May;124(3):7–15. PMID 22691894. Inadequate follow up time22691894
Kay GG, Staskin DR, MacDiarmid S, . Cognitive effects of oxybutynin chloride topical gel in older healthy subjects: a 1-week, randomized, double-blind, placebo- and active-controlled study. Clinical Drug Investigation. 2012 Oct 1;32(10):707–14. PMID 22909146. Inadequate follow up time22909146
Kean RJ, Lamport DJ, Dodd GF, . Chronic consumption of flavanone-rich orange juice is associated with cognitive benefits: an 8-wk, randomized, double-blind, placebo-controlled trial in healthy older adults. American Journal of Clinical Nutrition. 2015 Mar;101(3):506–14. PMID 25733635. Inadequate follow up time25733635
Kelly J, Fulford J, Vanhatalo A, . Effects of short-term dietary nitrate supplementation on blood pressure, O2 uptake kinetics, and muscle and cognitive function in older adults. American Journal of Physiology - Regulatory Integrative & Comparative Physiology. 2013 Jan 15;304(2):R73–83. PMID 23174856. Inadequate follow up time23174856
Kennedy DO, Dodd FL, Robertson BC, . Monoterpenoid extract of sage (Salvia lavandulaefolia) with cholinesterase inhibiting properties improves cognitive performance and mood in healthy adults. Journal of Psychopharmacology. 2011 Aug;25(8):1088–100. PMID 20937617. Inadequate follow up time20937617
Kennedy DO, Veasey RC, Watson AW, . Vitamins and psychological functioning: a mobile phone assessment of the effects of a B vitamin complex, vitamin C and minerals on cognitive performance and subjective mood and energy. Human Psychopharmacology. 2011 Jun–Jul;26(4–5):338–47. PMID 21751253. Inadequate follow up time21751253
Kennelly S, Abdullah L, Kenny RA, . Apolipoprotein e genotype-specific short-term cognitive benefits of treatment with the antihypertensive nilvadipine in Alzheimer’s patientsa-an open-label trial. International Journal of Geriatric Psychiatry. 2012 April;27(4):415–22. PMID 2012157085. Ineligible population21560164
Kennelly S, Abdullah L, Kenny RA, . Apolipoprotein E genotype-specific short-term cognitive benefits of treatment with the antihypertensive nilvadipine in Alzheimer’s patients--an open-label trial. International Journal of Geriatric Psychiatry. 2012 Apr;27(4):415–22. PMID 21560164. Ineligible population21560164
Kern S, Skoog I, Ostling S, . Does low-dose acetylsalicylic acid prevent cognitive decline in women with high cardiovascular risk? A 5-year follow-up of a non-demented population-based cohort of Swedish elderly women. BMJ Open. 2012;2(5) (no pagination)(e001288)PMID 2012683493. Not cognitive decline prevention intervention
Kersten H, Molden E, Tolo IK, . Cognitive effects of reducing anticholinergic drug burden in a frail elderly population: a randomized controlled trial. Journals of Gerontology Series A-Biological Sciences & Medical Sciences. 2013 Mar;68(3):271–8. PMID 22982689. Ineligible population22982689
Kesler S, Hadi Hosseini SM, Heckler C, . Cognitive training for improving executive function in chemotherapy-treated breast cancer survivors. Clinical Breast Cancer. 2013 Aug;13(4):299–306. PMID 23647804. Ineligible population23647804
Kesse-Guyot E, Andreeva VA, Lassale C, . Mediterranean diet and cognitive function: a French study. American Journal of Clinical Nutrition. 2013 Feb;97(2):369–76. PMID 23283500. Not cognitive decline prevention intervention23283500
Kesse-Guyot E, Andreeva VA, Touvier M, . Overall and abdominal adiposity in midlife and subsequent cognitive function. Journal of Nutrition, Health & Aging. 2015 Feb;19(2):183–9. PMID 25651444. Not cognitive decline prevention intervention25651444
Kessing LV, Forman JL, Andersen PK. Does lithium protect against dementia? Bipolar Disorders. 2010 Feb;12(1):87–94. PMID 20148870. Ineligible study design20148870
Khachaturian AS, Chapman J, Farrer L, . Healthy aging and preclinical dementia: the United States-Israel Longitudinal Database project. Alzheimer’s & Dementia. 2010 Nov;6(6):475–81. PMID 21044777. Ineligible study design21044777
Kim DH, Grodstein F, Rosner B, . Seafood types and age-related cognitive decline in the Women’s Health Study. Journals of Gerontology Series A-Biological Sciences & Medical Sciences. 2013 Oct;68(10):1255–62. PMID 23554464. Not cognitive decline prevention intervention23554464
Kim GH, Jeon S, Im K, . Structural brain changes after traditional and robot-assisted multi-domain cognitive training in community-dwelling healthy elderly. PLoS ONE. 2015 21 Apr;10(4)PMID 2015967293. Inadequate follow up time
Kim JM, Stewart R, Bae KY, . Role of BDNF val66met polymorphism on the association between physical activity and incident dementia. Neurobiology of Aging. 2011 Mar;32(3):551.e5–12. PMID 20172629. Not cognitive decline prevention intervention20172629
Kim SJ, Lee JH, Lee DY, . Neurocognitive dysfunction associated with sleep quality and sleep apnea in patients with mild cognitive impairment. American Journal of Geriatric Psychiatry. 2011 Apr;19(4):374–81. PMID 20808148. Ineligible study design20808148
Kim SY, Choi SH, Rollema H, . Phase II crossover trial of varenicline in mild-to-moderate Alzheimer’s disease. Dementia & Geriatric Cognitive Disorders. 2014;37(3–4):232–45. PMID 24247022. Ineligible population24247022
Kim YW, Shin JC, An YS. Changes in cerebral glucose metabolism in patients with posttraumatic cognitive impairment after memantine therapy: a preliminary study. Annals of Nuclear Medicine. 2010 Jun;24(5):363–9. PMID 20237871. Ineligible population20237871
Kinsella GJ, Mullaly E, Rand E, . Early intervention for mild cognitive impairment: a randomised controlled trial. Journal of Neurology, Neurosurgery & Psychiatry. 2009 Jul;80(7):730–6. PMID 19332424. Inadequate follow up time19332424
Kivipelto M, Solomon A, Ahtiluoto S, . The Finnish Geriatric Intervention Study to Prevent Cognitive Impairment and Disability (FINGER): study design and progress. Alzheimer’s & Dementia. 2013 Nov;9(6):657–65. PMID 23332672. Ineligible study design23332672
Klados MA, Styliadis C, Frantzidis CA, . Beta-band functional connectivity is reorganized in mild cognitive impairment after combined computerized physical and cognitive training. Frontiers in neuroscience. 2016;10. Inadequate follow up time26858590
Klepin HD, Geiger AM, Bandos H, . Cognitive factors associated with adherence to oral antiestrogen therapy: results from the cognition in the study of tamoxifen and raloxifene (Co-STAR) study. Cancer Prevention Research. 2014 Jan;7(1):161–8. PMID 24253314. No relevant outcomes reported24253314
Klusmann V, Evers A, Schwarzer R, . Activity experiences shape perceived fitness trajectories: results from a 6-month randomized controlled trial in older women. Aging Neuropsychology & Cognition. 2011 May;18(3):328–39. PMID 21557117. No relevant outcomes reported21557117
Ko HJ, Youn CH. Effects of laughter therapy on depression, cognition and sleep among the community-dwelling elderly. Geriatrics & gerontology international. 2011 Jul;11(3):267–74. PMID 21241447. Inadequate follow up time21241447
Kocoska-Maras L, Radestad AF, Carlstrom K, . Cognitive function in association with sex hormones in postmenopausal women. Gynecological Endocrinology. 2013 Jan;29(1):59–62. PMID 22967437. Inadequate follow up time22967437
Kocoska-Maras L, Zethraeus N, Radestad AF, . A randomized trial of the effect of testosterone and estrogen on verbal fluency, verbal memory, and spatial ability in healthy postmenopausal women. Fertility & Sterility. 2011 Jan;95(1):152–7. PMID 20667535. Inadequate follow up time20667535
Kohler S, Baars MA, Spauwen P, . Temporal evolution of cognitive changes in incident hypertension: prospective cohort study across the adult age span. Hypertension. 2014 Feb;63(2):245–51. PMID 24296281. Not cognitive decline prevention intervention24296281
Konagai C, Yanagimoto K, Hayamizu K, . Effects of krill oil containing n-3 polyunsaturated fatty acids in phospholipid form on human brain function: a randomized controlled trial in healthy elderly volunteers. Clinical Interventions In Aging. 2013;8:1247–57. PMID 24098072. Inadequate follow up time24098072
Kostis JB, Rosen RC, Wilson AC. Central nervous system effects of HMG CoA reductase inhibitors: lovastatin and pravastatin on sleep and cognitive performance in patients with hypercholesterolemia. Journal of Clinical Pharmacology. 1994 Oct;34(10):989–96. PMID 7836550. Inadequate follow up time7836550
Koushyar H, Najafi Z, Azhari A, . Comparison of the effect of fun and regular physical activity on the changes in the incidence of depression and cognitive disorders of elderly women living in nursing homes at Mashhad. [Persian]. Iranian Journal of Obstetrics, Gynecology and Infertility. 2014;17(132):1–9. PMID 2015761086. Not available in English
Krikorian R, Boespflug EL, Fleck DE, . Concord grape juice supplementation and neurocognitive function in human aging. Journal of Agricultural & Food Chemistry. 2012 Jun 13;60(23):5736–42. PMID 22468945. Inadequate follow up time22468945
Krikorian R, Eliassen JC, Boespflug EL, . Improved cognitive-cerebral function in older adults with chromium supplementation. Nutritional Neuroscience. 2010 Jun;13(3):116–22. PMID 20423560. Inadequate follow up time20423560
Krikorian R, Nash TA, Shidler MD, . Concord grape juice supplementation improves memory function in older adults with mild cognitive impairment. British Journal of Nutrition. 2010 Mar;103(5):730–4. PMID 20028599. Inadequate follow up time20028599
Krikorian R, Shidler MD, Nash TA, . Blueberry supplementation improves memory in older adults. Journal of Agricultural & Food Chemistry. 2010 Apr 14;58(7):3996–4000. PMID 20047325. Inadequate follow up time20047325
Kristensen PL, Hoi-Hansen T, Boomsma F, . Vascular endothelial growth factor during hypoglycemia in patients with type 1 diabetes mellitus: relation to cognitive function and renin-angiotensin system activity. Metabolism: Clinical & Experimental. 2009 Oct;58(10):1430–8. PMID 19573885. Not cognitive decline prevention intervention19573885
Krupp LB, Christodoulou C, Melville P, . Multicenter randomized clinical trial of donepezil for memory impairment in multiple sclerosis. Neurology. 2011 Apr 26;76(17):1500–7. PMID 21519001. Ineligible population21519001
Kryscio RJ, Abner EL, Schmitt FA, . A randomized controlled Alzheimer’s disease prevention trial’s evolution into an exposure trial: the PREADViSE Trial. Journal of Nutrition, Health & Aging. 2013 Jan;17(1):72–5. PMID 23299383. Ineligible study design23299383
Kulmala J, Solomon A, Kareholt I, . Association between mid- to late life physical fitness and dementia: evidence from the CAIDE study. Journal of Internal Medicine. 2014 Sep;276(3):296–307. PMID 24444031. Not cognitive decline prevention intervention24444031
Kurz A, Thone-Otto A, Cramer B, . CORDIAL: cognitive rehabilitation and cognitive-behavioral treatment for early dementia in Alzheimer disease: a multicenter, randomized, controlled trial. Alzheimer Disease & Associated Disorders. 2012 Jul–Sep;26(3):246–53. PMID 21986341. Ineligible population21986341
Kuster OC, Fissler P, Laptinskaya D, . Cognitive change is more positively associated with an active lifestyle than with training interventions in older adults at risk of dementia: A controlled interventional clinical trial. BMC Psychiatry. 2016 08 Sep;16 (1) (no pagination)(315)PMID 612014603. Inadequate follow up time
Kwok T, Lee J, Law CB, . A randomized placebo controlled trial of homocysteine lowering to reduce cognitive decline in older demented people. Clinical Nutrition. 2011 Jun;30(3):297–302. PMID 21216507. Ineligible population21216507
Kwok T, Wong A, Chan G, . Effectiveness of cognitive training for Chinese elderly in Hong Kong. Clinical Interventions In Aging. 2013;8:213–9. PMID 23440076. Inadequate follow up time23440076
Kwok TC, Lam LC, Sea MM, . A randomized controlled trial of dietetic interventions to prevent cognitive decline in old age hostel residents. European Journal of Clinical Nutrition. 2012 Oct;66(10):1135–40. PMID 22948946. Ineligible population22948946
Kwon JC, Kim EG, Kim JW, . A multicenter, open-label, 24-week follow-up study for efficacy on cognitive function of donepezil in Binswanger-type subcortical vascular dementia. American Journal of Alzheimer’s Disease & Other Dementias. 2009 Aug–Sep;24(4):293–301. PMID 19383979. Ineligible population19383979
Laforce R, Jr., Buteau JP, Paquet N, . The value of PET in mild cognitive impairment, typical and atypical/unclear dementias: A retrospective memory clinic study. American Journal of Alzheimer’s Disease & Other Dementias. 2010 Jun;25(4):324–32. PMID 20539026. Cohort study with inadequate sample size20539026
Laitala VS, Hjelmborg J, Koskenvuo M, . Shorter adult stature increases the impact of risk factors for cognitive impairment: a comparison of two Nordic twin cohorts. Twin Research & Human Genetics: the Official Journal of the International Society for Twin Studies. 2011 Dec;14(6):544–52. PMID 22506310. Ineligible study design22506310
Laitala VS, Kaprio J, Koskenvuo M, . Coffee drinking in middle age is not associated with cognitive performance in old age. American Journal of Clinical Nutrition. 2009 Sep;90(3):640–6. PMID 19587088. Not cognitive decline prevention intervention19587088
Lam JH. Can leisure activities slow dementia progression in nursing home residents? A cluster-randomized controlled trial. International psychogeriatrics / IPA. 2014 01 Apr;26(4):637–43. PMID 24411480. Ineligible population24411480
Lam LC, Chan WM, Kwok TC, . Effectiveness of Tai Chi in maintenance of cognitive and functional abilities in mild cognitive impairment: a randomised controlled trial. Hong Kong Medical Journal. 2014 Jun;20(3 Suppl 3):20–3. PMID 25001031. Ineligible population25001031
Lam LC, Chau RC, Wong BM, . Interim follow-up of a randomized controlled trial comparing Chinese style mind body (Tai Chi) and stretching exercises on cognitive function in subjects at risk of progressive cognitive decline. International Journal of Geriatric Psychiatry. 2011 Jul;26(7):733–40. PMID 21495078. Inadequate follow up time21495078
Lamport DJ, Saunders C, Butler LT, . Fruits, vegetables, 100% juices, and cognitive function. Nutrition Reviews. 2014 Dec;72(12):774–89. PMID 25399992. Ineligible study design25399992
Langballe EM, Ask H, Holmen J, . Alcohol consumption and risk of dementia up to 27 years later in a large, population-based sample: the HUNT study, Norway. European Journal of Epidemiology. 2015 Sep;30(9):1049–56. PMID 25968174. Not cognitive decline prevention intervention25968174
Langlois F, Vu TT, Chasse K, . Benefits of physical exercise training on cognition and quality of life in frail older adults. Journals of Gerontology Series B-Psychological Sciences & Social Sciences. 2013 May;68(3):400–4. PMID 22929394. Inadequate follow up time22929394
Lapid MI, Drake MT, Geske JR, . Hypovitaminosis D in psychogeriatric inpatients. Journal of Nutrition, Health & Aging. 2013 Mar;17(3):231–4. PMID 23459975. Cohort study with inadequate sample size23459975
Laudisio A, Marzetti E, Pagano F, . Digoxin and cognitive performance in patients with heart failure: A cohort, pharmacoepidemiological survey. Drugs and Aging. 2009;26(2):103–12. PMID 2009078141. Ineligible population19220067
Launer LJ, Hughes T, Yu B, . Lowering midlife levels of systolic blood pressure as a public health strategy to reduce late-life dementia: perspective from the Honolulu Heart Program/Honolulu Asia Aging Study. Hypertension. 2010 Jun;55(6):1352–9. PMID 20404223. Not cognitive decline prevention intervention20404223
Leduc V, De Beaumont L, Theroux L, . HMGCR is a genetic modifier for risk, age of onset and MCI conversion to Alzheimer’s disease in a three cohorts study. Molecular Psychiatry. 2015 24 Jul;20(7):867–73. PMID 2014735037. Not cognitive decline prevention intervention25023145
Lee ATC, Richards M, Chan WC, . Intensity and Types of Physical Exercise in Relation to Dementia Risk Reduction in Community-Living Older Adults. Journal of the American Medical Directors Association. 2015 01 Oct;16(10):899.e1–.e7. PMID 2015442379. Not cognitive decline prevention intervention
Lee CE, Kilgour A, Lau YK. Efficacy of walking exercise in promoting cognitive-psychosocial functions in men with prostate cancer receiving androgen deprivation therapy. BMC Cancer. 2012;12:324. PMID 22846379. Ineligible population22846379
Lee J, Pase M, Pipingas A, . Switching to a 10-day Mediterranean-style diet improves mood and cardiovascular function in a controlled crossover study. Nutrition. 2015 May;31(5):647–52. PMID 25837207. Inadequate follow up time25837207
Lee JG, Lee SW, Lee BJ, . Adjunctive memantine terapy for cognitive impairment in chronic schizophrenia: A placebo-controlled pilot study. Psychiatry Investigation. 2012;9(2):166–73. PMID 2012388152. Ineligible population22707968
Lee TS, Goh SJ, Quek SY, . A brain-computer interface based cognitive training system for healthy elderly: a randomized control pilot study for usability and preliminary efficacy. PLoS ONE [Electronic Resource]. 2013;8(11):e79419. PMID 24260218. Inadequate follow up time24260218
Lee TS, Quek SY, Goh SJ, . A pilot randomized controlled trial using EEG-based brain-computer interface training for a Chinese-speaking group of healthy elderly. Clinical Interventions In Aging. 2015;10:217–27. PMID 25624754. Inadequate follow up time25624754
Lee Y, Back JH, Kim J, . Systematic review of health behavioral risks and cognitive health in older adults. International Psychogeriatrics. 2010 Mar;22(2):174–87. PMID 19883522. Ineligible study design19883522
Lee Y, Kim J, Han ES, . Changes in physical activity and cognitive decline in older adults living in the community. Age. 2015;37(2)PMID 2015787853. Not cognitive decline prevention intervention
Lee YK, Hou SW, Lee CC, . Increased risk of dementia in patients with mild traumatic brain injury: a nationwide cohort study. PLoS ONE [Electronic Resource]. 2013;8(5):e62422. PMID 23658727. Ineligible population23658727
Legault C, Jennings JM, Katula JA, . Designing clinical trials for assessing the effects of cognitive training and physical activity interventions on cognitive outcomes: the Seniors Health and Activity Research Program Pilot (SHARP-P) study, a randomized controlled trial. BMC Geriatrics. 2011;11:27. PMID 21615936. Inadequate follow up time21615936
Lenz RA, Pritchett YL, Berry SM, . Adaptive, Dose-finding Phase 2 Trial Evaluating the Safety and Efficacy of ABT-089 in Mild to Moderate Alzheimer Disease. Alzheimer Disease and Associated Disorders. 2015 07 Sep;29(3):192–9. PMID 2015359676. Ineligible population25973909
Leoutsakos JM, Muthen BO, Breitner JC, . Effects of non-steroidal anti-inflammatory drug treatments on cognitive decline vary by phase of pre-clinical Alzheimer disease: findings from the randomized controlled Alzheimer’s Disease Anti-inflammatory Prevention Trial. International Journal of Geriatric Psychiatry. 2012 Apr;27(4):364–74. PMID 21560159. Ineligible study design21560159
Leufkens TR, Lund JS, Vermeeren A. Highway driving performance and cognitive functioning the morning after bedtime and middle-of-the-night use of gaboxadol, zopiclone and zolpidem. Journal of Sleep Research. 2009 Dec;18(4):387–96. PMID 19552733. Inadequate follow up time19552733
Leung GT, Fung AW, Tam CW, . Examining the association between participation in late-life leisure activities and cognitive function in community-dwelling elderly Chinese in Hong Kong. International Psychogeriatrics. 2010 Feb;22(1):2–13. PMID 19785918. Not cognitive decline prevention intervention19785918
Leung GT, Fung AW, Tam CW, . Examining the association between late-life leisure activity participation and global cognitive decline in community-dwelling elderly Chinese in Hong Kong. International Journal of Geriatric Psychiatry. 2011 Jan;26(1):39–47. PMID 21157849. Not cognitive decline prevention intervention21157849
Levin OS, Yunishchenko NA, Dudarova MA. Efficacy of akatinol memantine in moderate cognitive impairments. Neuroscience & Behavioral Physiology. 2010 Oct;40(8):926–33. PMID 20683775. Ineligible study design20683775
Lewis JE, McDaniel HR, Agronin ME, . The effect of an aloe polymannose multinutrient complex on cognitive and immune functioning in Alzheimer’s disease. Journal of Alzheimer’s Disease. 2013;33(2):393–406. PMID 22976077. Ineligible population22976077
Li F, Harmer P, Liu Y, . Tai Ji Quan and global cognitive function in older adults with cognitive impairment: a pilot study. Archives of Gerontology & Geriatrics. 2014 May–Jun;58(3):434–9. PMID 24398166. Inadequate follow up time24398166
Li G, Shofer JB, Rhew IC, . Age-varying association between statin use and incident Alzheimer’s disease. Journal of the American Geriatrics Society. 2010 Jul;58(7):1311–7. PMID 20533968. Not cognitive decline prevention intervention20533968
Li NC, Lee A, Whitmer RA, . Use of angiotensin receptor blockers and risk of dementia in a predominantly male population: Prospective cohort analysis. BMJ (Online). 2010 16 Jan;340(7738):141. PMID 2010062843. Not cognitive decline prevention intervention
Li R, Polat U, Makous W, . Enhancing the contrast sensitivity function through action video game training. Nature Neuroscience. 2009 May;12(5):549–51. PMID 19330003. Inadequate follow up time19330003
Li R, Polat U, Scalzo F, . Reducing backward masking through action game training. Journal of Vision. 2010;10(14)PMID 21191129. Ineligible study design21191129
Liang J, Li F, Wei C, . Rationale and design of a multicenter, phase 2 clinical trial to investigate the efficacy of traditional Chinese medicine sailuotong in vascular dementia. Journal of Stroke and Cerebrovascular Diseases. 2014;23(10):2626–34. PMID 2014873944. Ineligible study design25294055
Liao JN, Chao TF, Liu CJ, . Risk and prediction of dementia in patients with atrial fibrillation - A nationwide population-based cohort study. International Journal of Cardiology. 2015 15 Sep;199:25–30. PMID 2015376315. Ineligible population26173170
Liao KM, Ho CH, Ko SC, . Increased Risk of Dementia in Patients With Chronic Obstructive Pulmonary Disease. Medicine. 2015 Jun;94(23):e930. PMID 26061317. Ineligible population26061317
Liao MT, Lin LY, Yang YH, . ACEI and ARB did not reduce the incidence of dementia in patients with atrial fibrillation: A nationwide cohort study. Acta Cardiologica Sinica. 2013 July;29(4):323–7. PMID 2013464598. Ineligible population27122725
Licastro F, Porcellini E, Chiappelli M, . Multivariable network associated with cognitive decline and dementia. Neurobiology of Aging. 2010 February;31(2):257–69. PMID 2009623669. Not cognitive decline prevention intervention18485535
Lieb W, Beiser AS, Vasan RS, . Association of plasma leptin levels with incident Alzheimer disease and MRI measures of brain aging. JAMA - Journal of the American Medical Association. 2009 16 Dec;302(23):2565–72. PMID 2009657832. Ineligible study design20009056
Lim AS, Yu L, Kowgier M, . Modification of the relationship of the apolipoprotein E epsilon4 allele to the risk of Alzheimer disease and neurofibrillary tangle density by sleep. JAMA Neurology. 2013 Dec;70(12):1544–51. PMID 24145819. Not cognitive decline prevention intervention24145819
Lin CC, Chou CH, Fan YM, . Increased risk of dementia among sleep-related movement disorders: A population-based longitudinal study in Taiwan. Medicine (United States). 2015;94(51) (no pagination)(e2331)PMID 20160007822. Not cognitive decline prevention intervention
Lin CH, Chen PK, Chang YC, . Benzoate, a D-amino acid oxidase inhibitor, for the treatment of early-phase Alzheimer disease: a randomized, double-blind, placebo-controlled trial. Biological Psychiatry. 2014 May 1;75(9):678–85. PMID 24074637. Ineligible population24074637
Lin CH, Sheu WHH. Hypoglycaemic episodes and risk of dementia in diabetes mellitus: 7-year follow-up study. Journal of Internal Medicine. 2013 January;273(1):102–10. PMID 2013003846. Not cognitive decline prevention intervention23003116
Lin F, Heffner KL, Ren P, . Cognitive and Neural Effects of Vision-Based Speed-of-Processing Training in Older Adults with Amnestic Mild Cognitive Impairment: A Pilot Study. Journal of the American Geriatrics Society. 2016;64(6):1293–8. Inadequate follow up time27321608
Lin JN, Lin CL, Lin MC, . Increased Risk of Dementia in Patients With Acute Organophosphate and Carbamate Poisoning: A Nationwide Population-Based Cohort Study. Medicine. 2015 Jul;94(29):e1187. PMID 26200627. Not cognitive decline prevention intervention26200627
Lindenmayer JP, Khan A. Galantamine augmentation of long-acting injectable risperidone for cognitive impairments in chronic schizophrenia. Schizophrenia Research. 2011 February;125(2–3):267–77. PMID 2011052376. Ineligible population20850275
Lippa CF, Rosso A, Hepler M, . Levetiracetam: a practical option for seizure management in elderly patients with cognitive impairment. American Journal of Alzheimer’s Disease & Other Dementias. 2010 Mar;25(2):149–54. PMID 19001351. Inadequate follow up time19001351
Lipton RB, Hirsch J, Katz MJ, . Exceptional parental longevity associated with lower risk of Alzheimer’s disease and memory decline. Journal of the American Geriatrics Society. 2010 Jun;58(6):1043–9. PMID 20487085. Cohort study with inadequate sample size20487085
Littlejohns TJ, Henley WE, Lang IA, . Vitamin D and the risk of dementia and Alzheimer disease. Neurology. 2014 Sep 2;83(10):920–8. PMID 25098535. Not cognitive decline prevention intervention25098535
Litvinenko IV, Vorob’ev SV, Lobzin VY, . Possibilities of pharmacological modulation of brain glutamatergic system in the treatment of vascular cognitive impairment. [Russian]. Zhurnal Nevrologii i Psihiatrii imeni S.S. 2013;Korsakova. 2013(9):29–35. PMID 2014590162. Not available in English
Litvinenko IV, Vorob’ev SV, Lobzin VY, . Possibilities of pharmacological modulation of brain glutamatergic system in the treatment of vascular cognitive impairment. Zhurnal Nevrologii i Psihiatrii imeni S.S. 2013;Korsakova. 2013(9):29–35. PMID 2013654201. Ineligible population
Liu C, Zeng CL, Zhen LR. Effects of HMG-CoA reductase inhibitors on primary hypertension patients with vascular cognitive impairment. [Chinese]. Chinese Pharmaceutical Journal. 2010 May;45(9):706–9. PMID 2010492740. Not available in English
Liu YH, Wang DX, Li LH, . The effects of cardiopulmonary bypass on the number of cerebral microemboli and the incidence of cognitive dysfunction after coronary artery bypass graft surgery. Anesthesia & Analgesia. 2009 Oct;109(4):1013–22. PMID 19762724. Cohort study with inadequate sample size19762724
Liu-Ambrose T, Donaldson MG. Exercise and cognition in older adults: is there a role for resistance training programmes? British Journal of Sports Medicine. 2009 Jan;43(1):25–7. PMID 19019904. Ineligible study design19019904
Liu-Ambrose T, Eng JJ, Boyd LA, . Promotion of the mind through exercise (PROMoTE): a proof-of-concept randomized controlled trial of aerobic exercise training in older adults with vascular cognitive impairment. BMC Neurology. 2010;10:14. PMID 20158920. Ineligible study design20158920
Llamas-Velasco S, Contador I, Villarejo-Galende A, . Physical activity as protective factor against dementia: A prospective population-based study (NEDICES). Journal of the International Neuropsychological Society. 2015 Nov;21(10):861–7. PMID 2015-53115-014. Ineligible study design26581797
Lobo E, Dufouil C, Marcos G, . Is there an association between low-to-moderate alcohol consumption and risk of cognitive decline? American Journal of Epidemiology. 2010 Sep 15;172(6):708–16. PMID 20699263. Not cognitive decline prevention intervention20699263
Loef M, Walach H. Fruit, vegetables and prevention of cognitive decline or dementia: a systematic review of cohort studies. Journal of Nutrition, Health & Aging. 2012 Jul;16(7):626–30. PMID 22836704. Ineligible study design22836704
Loewenstein DA, Acevedo A, Czaja SJ, . Cognitive rehabilitation of mildly impaired Alzheimer disease patients on cholinesterase inhibitors. American Journal of Geriatric Psychiatry. 2004 Jul–Aug;12(4):395–402. PMID 15249277. Ineligible population15249277
Lohman MC, Rebok GW, Spira AP, . Depressive symptoms and memory performance among older adults: results from the ACTIVE memory training intervention. Journal of Aging & Health. 2013 Dec;25(8 Suppl):209S–29S. PMID 23006426. Not cognitive decline prevention intervention23006426
Lopez LB, Kritz-Silverstein D, Barrett Connor E. High dietary and plasma levels of the omega-3 fatty acid docosahexaenoic acid are associated with decreased dementia risk: the Rancho Bernardo study. Journal of Nutrition, Health & Aging. 2011 Jan;15(1):25–31. PMID 21267518. Cohort study with inadequate sample size21267518
Louis ED, Benito-Leon J, Bermejo-Pareja F, . Antihypertensive agents and risk of Parkinson’s disease, essential tremor and dementia: a population-based prospective study (NEDICES). Neuroepidemiology. 2009;33(3):286–92. PMID 19696520. Not cognitive decline prevention intervention19696520
Lovell MA, Abner E, Kryscio R, . Calcium Channel Blockers, Progression to Dementia, and Effects on Amyloid Beta Peptide Production. Oxidative Medicine and Cellular Longevity. 2015;2015 (no pagination)(787805)PMID 2015195362. Not cognitive decline prevention intervention
Lovestone S, Boada M, Dubois B, . A phase II trial of tideglusib in alzheimer’s disease. Journal of Alzheimer’s Disease. 2015;45(1):75–88. PMID 2015808408. Ineligible population
Lovheim H, Gilthorpe J, Adolfsson R, . Reactivated herpes simplex infection increases the risk of Alzheimer’s disease. Alzheimer’s and Dementia. 2015 01 Jun;11(6):593–9. PMID 2014736948. Not cognitive decline prevention intervention
Low LF, Anstey KJ, Sachdev P. Use of medications with anticholinergic properties and cognitive function in a young-old community sample. International Journal of Geriatric Psychiatry. 2009 Jun;24(6):578–84. PMID 19021151. Not cognitive decline prevention intervention19021151
Lu PH, Edland SD, Teng E, . Donepezil delays progression to AD in MCI subjects with depressive symptoms. Neurology. 2009 Jun 16;72(24):2115–21. PMID 19528519. No relevant outcomes reported19528519
Lu PH, Masterman DA, Mulnard R, . Effects of testosterone on cognition and mood in male patients with mild Alzheimer disease and healthy elderly men. Arch Neurol. 2006 Feb;63(2):177–85. PMID 16344336. Ineligible population16344336
Luck T, Luppa M, Angermeyer MC, . Impact of impairment in instrumental activities of daily living and mild cognitive impairment on time to incident dementia: results of the Leipzig Longitudinal Study of the Aged. Psychological Medicine. 2011 May;41(5):1087–97. PMID 20667169. Ineligible study design20667169
Luck T, Luppa M, Wiese B, . Prediction of incident dementia: impact of impairment in instrumental activities of daily living and mild cognitive impairment-results from the German study on ageing, cognition, and dementia in primary care patients. American Journal of Geriatric Psychiatry. 2012 Nov;20(11):943–54. PMID 22706332. Not cognitive decline prevention intervention22706332
Luck T, Riedel-Heller SG, Luppa M, . Apolipoprotein E epsilon 4 genotype and a physically active lifestyle in late life: analysis of gene-environment interaction for the risk of dementia and Alzheimer’s disease dementia. Psychological Medicine. 2014 Apr;44(6):1319–29. PMID 23883793. Not cognitive decline prevention intervention23883793
Luck T, Riedel-Heller SG, Luppa M, . Risk factors for incident mild cognitive impairment--results from the German Study on Ageing, Cognition and Dementia in Primary Care Patients (AgeCoDe). Acta Psychiatrica Scandinavica. 2010 Apr;121(4):260–72. PMID 19824992. Not cognitive decline prevention intervention19824992
Luttenberger K, Hofner B, Graessel E. Are the effects of a non-drug multimodal activation therapy of dementia sustainable? Follow-up study 10 months after completion of a randomised controlled trial. BMC Neurology. 2012;12:151. PMID 23217188. Ineligible population23217188
Lynga P, Persson H, Hagg-Martinell A, . Weight monitoring in patients with severe heart failure (WISH). A randomized controlled trial. European Journal of Heart Failure. 2012 Apr;14(4):438–44. PMID 22371525. No relevant outcomes reported22371525
Ma F, Wu T, Miao R, . Conversion of mild cognitive impairment to dementia among subjects with diabetes: a population-based study of incidence and risk factors with five years of follow-up. Journal of Alzheimer’s Disease. 2015;43(4):1441–9. PMID 25159674. Not cognitive decline prevention intervention25159674
Mahdavi A, Besharat MA, Taghizadeh ME, . Effectiveness of multi-sensory stimulations upon restoration of cognitive performance of patients exposed vascular dementia. Der Pharmacia Lettre. 2015;7(7):19–22. PMID 2015257115. Ineligible population
Maher-Edwards G, De’Ath J, Barnett C, . A 24-week study to evaluate the effect of rilapladib on cognition and cerebrospinal fluid biomarkers of Alzheimer’s disease. Alzheimer’s and Dementia: Translational Research and Clinical Interventions. 2015 15 Oct;1(2):131–40. PMID 2015445710. Ineligible population
Maher-Edwards G, Dixon R, Hunter J, . SB-742457 and donepezil in Alzheimer disease: a randomized, placebo-controlled study. International Journal of Geriatric Psychiatry. 2011 May;26(5):536–44. PMID 20872778. Ineligible population20872778
Maher-Edwards G, Watson C, Ascher J, . Two randomized controlled trials of SB742457 in mild-to-moderate Alzheimer’s disease. Alzheimer’s and Dementia: Translational Research and Clinical Interventions. 2015 14 Oct;1(1):23–36. PMID 2015441551. Ineligible population
Maher-Edwards G, Zvartau-Hind M, Hunter AJ, . Double-blind, controlled phase ii study of a 5-ht6 receptor antagonist, sb-742457, in alzheimer’s disease. Current Alzheimer Research. 2010;7(5):374–85. PMID 2010637453. Ineligible population20043816
Mahncke HW, Bronstone A, Merzenich MM. Brain plasticity and functional losses in the aged: scientific bases for a novel intervention. Progress in Brain Research. 2006;157:81–109. PMID 17046669. Ineligible study design17046669
Mahncke HW, Connor BB, Appelman J, . Memory enhancement in healthy older adults using a brain plasticity-based training program: a randomized, controlled study. Proceedings of the National Academy of Sciences of the United States of America. 2006 Aug 15;103(33):12523–8. PMID 16888038. Inadequate follow up time16888038
Maillot P, Perrot A, Hartley A. Effects of interactive physical-activity video-game training on physical and cognitive function in older adults. Psychology & Aging. 2012 Sep;27(3):589–600. PMID 22122605. Inadequate follow up time22122605
Maki PM. A systematic review of clinical trials of hormone therapy on cognitive function: effects of age at initiation and progestin use. Ann N Y Acad Sci. 2005 Jun;1052:182–97. PMID 16024761. Ineligible study design16024761
Maki PM, Dennerstein L, Clark M, . Perimenopausal use of hormone therapy is associated with enhanced memory and hippocampal function later in life. Brain Research. 2011 Mar 16;1379:232–43. PMID 21078303. Cohort study with inadequate sample size21078303
Maki PM, Henderson VW. Hormone therapy, dementia, and cognition: the Women’s Health Initiative 10 years on. Climacteric. 2012 Jun;15(3):256–62. PMID 22612612. Ineligible study design22612612
Makino KM, Porsteinsson AP. Memantine: A treatment for Alzheimers disease with a new formulation. Aging Health. 2011 June;7(3):349–62. PMID 2011351492. Ineligible study design
Makizako H, Doi T, Shimada H, . Does a multicomponent exercise program improve dual-task performance in amnestic mild cognitive impairment? A randomized controlled trial. Aging-Clinical & Experimental Research. 2012 Dec;24(6):640–6. PMID 23211228. No relevant outcomes reported23211228
Malkki H. Dementia: New study puts its FINGER on prevention of cognitive decline. Nature Reviews Neurology. 2015 11 May;11(5):248. PMID 2015865264. Ineligible study design
Mamikonyan E, Xie SX, Melvin E, . Rivastigmine for mild cognitive impairment in Parkinson disease: A placebo-controlled study. Movement Disorders. 2015 01 Jun;30(7):912–8. PMID 2015970313. Ineligible population25914281
Mammarella N, Fairfield B. Where did I put my keys? - a ‘we’ intervention to promote memory in healthy older adults: a controlled pilot study. Gerontology. 2013;59(4):349–54. PMID 23364128. Inadequate follow up time23364128
Man DW, Chung JC, Lee GY. Evaluation of a virtual reality-based memory training programme for Hong Kong Chinese older adults with questionable dementia: a pilot study. International Journal of Geriatric Psychiatry. 2012 May;27(5):513–20. PMID 21681818. Ineligible population21681818
Manenti R, Brambilla M, Petesi M, . Enhancing verbal episodic memory in older and young subjects after non-invasive brain stimulation. Frontiers in Aging Neuroscience. 2013;5(SEP)PMID 2014170746. Inadequate follow up time
Mangialasche F, Solomon A, Kareholt I, . Serum levels of vitamin E forms and risk of cognitive impairment in a Finnish cohort of older adults. Experimental Gerontology. 2013 Dec;48(12):1428–35. PMID 24113154. Cohort study with inadequate sample size24113154
Mannikko R, Komulainen P, Schwab U, . The Nordic diet and cognition--The DR’s EXTRA Study. British Journal of Nutrition. 2015 Jul;114(2):231–9. PMID 26104270. No relevant outcomes reported26104270
Marek GJ, Katz DA, Meier A, . Efficacy and safety evaluation of HSD-1 inhibitor ABT-384 in Alzheimer’s disease. Alzheimer’s & Dementia. 2014 Oct;10(5 Suppl):S364–73. PMID 24418055. Ineligible population24418055
Marmeleira JF, Godinho MB, Fernandes OM. The effects of an exercise program on several abilities associated with driving performance in older adults. Accident Analysis & Prevention. 2009 Jan;41(1):90–7. PMID 19114142. Inadequate follow up time19114142
Marra HLD, Myczkowski ML, Memoria CM, . Transcranial magnetic stimulation to address mild cognitive impairment in the elderly: A randomized controlled study. Behavioural Neurology. 2015;2015:287843. PMID 2015-27339-001. Inadequate follow up time26160997
Marshall GA, Zoller AS, Lorius N, . Functional activities questionnaire items that best discriminate and predict progression from clinically normal to mild cognitive impairment. Current Alzheimer Research. 2015;12(5):493–502. PMID 2015125099. Ineligible study design26017560
Marzona I, O’Donnell M, Teo K, . Increased risk of cognitive and functional decline in patients with atrial fibrillation: results of the ONTARGET and TRANSCEND studies. CMAJ Canadian Medical Association Journal. 2012 Apr 3;184(6):E329–36. PMID 22371515. No relevant outcomes reported22371515
Mastroiacovo D, Kwik-Uribe C, Grassi D, . Cocoa flavanol consumption improves cognitive function, blood pressure control, and metabolic profile in elderly subjects: the Cocoa, Cognition, and Aging (CoCoA) Study--a randomized controlled trial. American Journal of Clinical Nutrition. 2015 Mar;101(3):538–48. PMID 25733639. Inadequate follow up time25733639
Matousek RH, Sherwin BB. A randomized controlled trial of add-back estrogen or placebo on cognition in men with prostate cancer receiving an antiandrogen and a gonadotropin-releasing hormone analog. Psychoneuroendocrinology. 2010 Feb;35(2):215–25. PMID 19615826. Inadequate follow up time19615826
Mavaddat N, Roalfe A, Fletcher K, . Warfarin versus aspirin for prevention of cognitive decline in atrial fibrillation: randomized controlled trial (Birmingham Atrial Fibrillation Treatment of the Aged Study). Stroke. 2014 May;45(5):1381–6. PMID 24692475. Ineligible population24692475
Mayas J, Parmentier FB, Andres P, . Plasticity of attentional functions in older adults after non-action video game training: a randomized controlled trial. PLoS ONE [Electronic Resource]. 2014;9(3):e92269. PMID 24647551. Inadequate follow up time24647551
McGuinness B, Fuchs M, Barrett SL, . Platelet membrane beta-secretase activity in mild cognitive impairment and conversion to dementia: A longitudinal study. Journal of Alzheimer’s Disease. 2015 24 Dec;49(4):1095–103. PMID 20160029198. Cohort study with inadequate sample size
McIntyre RS, Lophaven S, Olsen CK. A randomized, double-blind, placebo-controlled study of vortioxetine on cognitive function in depressed adults. International Journal of Neuropsychopharmacology. 2014 Oct;17(10):1557–67. PMID 24787143. Inadequate follow up time24787143
Meador KJ, Gevins A, Leese PT, . Neurocognitive effects of brivaracetam, levetiracetam, and lorazepam. Epilepsia. 2011 Feb;52(2):264–72. PMID 20887370. Inadequate follow up time20887370
Mechaeil R, Gard P, Jackson A, . Cognitive enhancement following acute losartan in normotensive young adults. Psychopharmacology. 2011 Sep;217(1):51–60. PMID 21484242. Inadequate follow up time21484242
Mecocci P, Bladstrom A, Stender K. Effects of memantine on cognition in patients with moderate to severe Alzheimer’s disease: post-hoc analyses of ADAS-cog and SIB total and single-item scores from six randomized, double-blind, placebo-controlled studies. International Journal of Geriatric Psychiatry. 2009 May;24(5):532–8. PMID 19274640. Ineligible population19274640
Mehlig K, Skoog I, Waern M, . Physical activity, weight status, diabetes and dementia: a 34-year follow-up of the population study of women in Gothenburg. Neuroepidemiology. 2014;42(4):252–9. PMID 24923622. Not cognitive decline prevention intervention24923622
Meinzer M, Antonenko D, Lindenberg R, . Electrical brain stimulation improves cognitive performance by modulating functional connectivity and task-specific activation. Journal of Neuroscience. 2012 Feb 1;32(5):1859–66. PMID 22302824. Not cognitive decline prevention intervention22302824
Meinzer M, Lindenberg R, Antonenko D, . Anodal transcranial direct current stimulation temporarily reverses age-associated cognitive decline and functional brain activity changes. Journal of Neuroscience. 2013 Jul 24;33(30):12470–8. PMID 23884951. Inadequate follow up time23884951
Meinzer M, Lindenberg R, Phan MT, . Transcranial direct current stimulation in mild cognitive impairment: Behavioral effects and neural mechanisms. Alzheimer’s and Dementia. 2015 01 Sep;11(9):1032–40. PMID 2015397617. Inadequate follow up time
Meiron O, Lavidor M. Prefrontal oscillatory stimulation modulates access to cognitive control references in retrospective metacognitive commentary. Clinical Neurophysiology. 2014 Jan;125(1):77–82. PMID 23831184. Inadequate follow up time23831184
Mejia-Arango S, Zuniga-Gil C. Diabetes mellitus as a risk factor for dementia in the mexican elder population Diabetes mellitus como factor de riesgo de demencia en la poblacion adulta mayor mexicana. Revista de Neurologia. 2011;53(7):397–405. PMID 2011559427. Not available in English21948010
Melloni M, Sedeno L, Couto B, . Preliminary evidence about the effects of meditation on interoceptive sensitivity and social cognition. Behavioral & Brain Functions [Electronic Resource]: BBF. 2013;9:47. PMID 24365106. Inadequate follow up time24365106
Merchant RA, Li B, Yap KB, . Use of drugs with anticholinergic effects and cognitive impairment in community-living older persons. Age & Ageing. 2009 Jan;38(1):105–8. PMID 19008305. Not cognitive decline prevention intervention19008305
Merritt P, Stangl B, Hirshman E, . Administration of dehydroepiandrosterone (DHEA) increases serum levels of androgens and estrogens but does not enhance short-term memory in post-menopausal women. Brain Research. 2012 Nov 5;1483:54–62. PMID 22985672. Inadequate follow up time22985672
Miao YC, Tian JZ, Shi J, . Effects of Chinese medicine for tonifying the kidney and resolving phlegm and blood stasis in treating patients with amnestic mild cognitive impairment: a randomized, double-blind and parallel-controlled trial. Zhong Xi Yi Jie He Xue Bao/Journal of Chinese Integrative Medicine. 2012 Apr;10(4):390–7. PMID 22500712. Inadequate follow up time22500712
Middleton LE, Manini TM, Simonsick EM, . Activity energy expenditure and incident cognitive impairment in older adults. Archives of Internal Medicine. 2011 Jul 25;171(14):1251–7. PMID 21771893. Cohort study with inadequate sample size21771893
Miettinen PS, Jauhiainen AM, Tarkka IM, . Long-term response to cholinesterase inhibitor treatment is related to functional MRI response in Alzheimer’s disease. Dementia and Geriatric Cognitive Disorders. 2015 14 Oct;40(5–6):243–55. PMID 2015348323. Ineligible population26305064
Milte CM, Sinn N, Street SJ, . Erythrocyte polyunsaturated fatty acid status, memory, cognition and mood in older adults with mild cognitive impairment and healthy controls. Prostaglandins Leukotrienes & Essential Fatty Acids. 2011 May–Jun;84(5–6):153–61. PMID 21392955. Not cognitive decline prevention intervention21392955
Mintzer MZ, Kleykamp BA, Griffiths RR. Dose Effects of Triazolam and Scopolamine on Metamemory. Experimental and Clinical Psychopharmacology. 2010 February;18(1):17–31. PMID 2010110883. Inadequate follow up time20158291
Mishra J, de Villers-Sidani E, Merzenich M, . Adaptive training diminishes distractibility in aging across species. Neuron. 2014 Dec 3;84(5):1091–103. PMID 25467987. Ineligible population25467987
Mishra J, Gazzaley A. Cross-species approaches to cognitive neuroplasticity research. NeuroImage. 2016;131:4–12. Ineligible population26348561
Mishra J, Rolle C, Gazzaley A. Neural plasticity underlying visual perceptual learning in aging. Brain Research. 2015 Jul 1;1612:140–51. PMID 25218557. Inadequate follow up time25218557
Miwa K, Tanaka M, Okazaki S, . Increased total homocysteine levels predict the risk of incident dementia independent of cerebral small-vessel diseases and vascular risk factors. Journal of Alzheimer’s Disease. 2015 09 Oct;49(2):503–13. PMID 2015551994. Not cognitive decline prevention intervention
Miyoshi I, Fujimoto Y, Yamada M, . Safety and pharmacokinetics of PF-04360365 following a single-dose intravenous infusion in Japanese subjects with mild-to-moderate Alzheimer’s disease: a multicenter, randomized, double-blind, placebo-controlled, dose-escalation study. International Journal of Clinical Pharmacology & Therapeutics. 2013 Dec;51(12):911–23. PMID 24131736. Ineligible population24131736
Modrego PJ, Fayed N, Errea JM, . Memantine versus donepezil in mild to moderate Alzheimer’s disease: a randomized trial with magnetic resonance spectroscopy. European Journal of Neurology. 2010 Mar;17(3):405–12. PMID 19874395. Ineligible population19874395
Mohagheghi A, Arfaie A, Amiri S, . Preventive effect of liothyronine on electroconvulsive therapy-induced memory deficit in patients with major depressive disorder: a double-blind controlled clinical trial. BioMed Research International. 2015;2015:503918. PMID 25945337. Ineligible population25945337
Mohs RC, Shiovitz TM, Tariot PN, . Atomoxetine augmentation of cholinesterase inhibitor therapy in patients with Alzheimer disease: 6-month, randomized, double-blind, placebo-controlled, parallel-trial study. American Journal of Geriatric Psychiatry. 2009 Sep;17(9):752–9. PMID 19700948. Ineligible population19700948
Mokhova OI. [The use of reminyl (galantamine) in the treatment of probable vascular dementia]. Zhurnal Nevrologii i Psikhiatrii Imeni S.S. Korsakova. 2009;109(9):77–9. PMID 19911468. Not available in English19911468
Molinuevo JL, Berthier ML, Rami L. Donepezil provides greater benefits in mild compared to moderate Alzheimer’s disease: implications for early diagnosis and treatment. Archives of Gerontology & Geriatrics. 2011 Jan–Feb;52(1):18–22. PMID 19948364. Ineligible population19948364
Molinuevo JL, Frolich L, Grossberg GT, . Responder analysis of a randomized comparison of the 13.3 mg/24 h and 9.5 mg/24 h rivastigmine patch. Alzheimer’s Research and Therapy. 2015 08 Mar;7(1)PMID 2015957412. Ineligible population
Montine TJ, Sonnen JA, Montine KS, . Adult changes in thought study: Dementia is an individually varying convergent syndrome with prevalent clinically silent diseases that may be modified by some commonly used therapeutics. Current Alzheimer Research. 2012 July;9(6):718–23. PMID 2012391770. Ineligible study design22471861
Moon JH, Lim S, Han JW, . Serum 25-hydroxyvitamin D level and the risk of mild cognitive impairment and dementia: The Korean Longitudinal Study on Health and Aging (KLoSHA). Clinical Endocrinology. 2015 01 Jul;83(1):36–42. PMID 2015796039. Cohort study with inadequate sample size25641087
Moon SY, Na DL, Seo SW, . Impact of white matter changes on activities of daily living in mild to moderate dementia. European Neurology. 2011 April;65(4):223–30. PMID 2011224387. Ineligible population21447954
Moore EM, Mander AG, Ames D, . Increased risk of cognitive impairment in patients with diabetes is associated with metformin. Diabetes Care. 2013 October;36(10):2981–7. PMID 2014022050. Ineligible population24009301
Moore EM, Mander AG, Ames D, . Increased risk of cognitive impairment in patients with diabetes is associated with metformin.[Erratum appears in Diabetes Care. 2013 Nov;36(11):3850]. Diabetes Care. 2013 Oct;36(10):2981–7. PMID 24009301. Ineligible population24009301
Morgan GS, Gallacher J, Bayer A, . Physical activity in middle-age and dementia in later life: findings from a prospective cohort of men in Caerphilly, South Wales and a meta-analysis. Journal of Alzheimer’s Disease. 2012;31(3):569–80. PMID 22647258. Not cognitive decline prevention intervention22647258
Morillas-Ruiz JM, Rubio-Perez JM, Albaladejo MD, . Effect of an antioxidant drink on homocysteine levels in Alzheimer’s patients. Journal of the Neurological Sciences. 2010 Dec 15;299(1–2):175–8. PMID 20850133. Ineligible population20850133
Morimoto BH, Schmechel D, Hirman J, . A double-blind, placebo-controlled, ascending-dose, randomized study to evaluate the safety, tolerability and effects on cognition of AL-108 after 12 weeks of intranasal administration in subjects with mild cognitive impairment. Dementia & Geriatric Cognitive Disorders. 2013;35(5–6):325–36. PMID 23594991. Inadequate follow up time23594991
Moro V, Condoleo MT, Valbusa V, . Cognitive stimulation of executive functions in mild cognitive impairment: Specific efficacy and impact in memory. American Journal of Alzheimer’s Disease and other Dementias. 2015 25 Mar;30(2):153–64. PMID 2015867211. Ineligible study design
Morris MC, Tangney CC, Wang Y, . MIND diet slows cognitive decline with aging. Alzheimer’s and Dementia. 2015 01 Sep;11(9):1015–22. PMID 2015186686. Not cognitive decline prevention intervention
Morris MC, Tangney CC, Wang Y, . MIND diet associated with reduced incidence of Alzheimer’s disease. Alzheimer’s and Dementia. 2015 01 Sep;11(9):1007–14. PMID 2015807456. Not cognitive decline prevention intervention
Moss DE, Fariello RG, Sahlmann J, . A randomized phase I study of methanesulfonyl fluoride, an irreversible cholinesterase inhibitor, for the treatment of Alzheimer’s disease. British Journal of Clinical Pharmacology. 2013 May;75(5):1231–9. PMID 2013232518. Inadequate follow up time23116458
Mowszowski L, Hermens DF, Diamond K, . Cognitive training enhances pre-attentive neurophysiological responses in older adults ‘at risk’ of dementia. Journal of Alzheimer’s Disease. 2014;41(4):1095–108. PMID 24787916. Inadequate follow up time24787916
Mozolic JL, Long AB, Morgan AR, . A cognitive training intervention improves modality-specific attention in a randomized controlled trial of healthy older adults. Neurobiology of Aging. 2011 Apr;32(4):655–68. PMID 19428142. Inadequate follow up time19428142
Mrazek MD, Franklin MS, Phillips DT, . Mindfulness training improves working memory capacity and GRE performance while reducing mind wandering. Psychological Science. 2013 May;24(5):776–81. PMID 23538911. Inadequate follow up time23538911
Muller U, Rowe JB, Rittman T, . Effects of modafinil on non-verbal cognition, task enjoyment and creative thinking in healthy volunteers. Neuropharmacology. 2013 Jan;64:490–5. PMID 22820554. Inadequate follow up time22820554
Muniz R, Serra CM, Reisberg B, . Cognitive-motor intervention in alzheimer’s disease: Long-term results from the maria wolff trial. Journal of Alzheimer’s Disease. 2015;45(1):295–304. PMID 2015808400. Ineligible population
Muniza R, Serraa CM, Reisberga B, . Cognitive-motor intervention in Alzheimer’s disease: Long-term results from the Maria Wolff trial. Journal of Alzheimer’s Disease. 2015;45(1):295–304. Ineligible population
Murphy GM, Jr., Sarginson JE, Ryan HS, . BDNF and CREB1 genetic variants interact to affect antidepressant treatment outcomes in geriatric depression. Pharmacogenetics and Genomics. 2013 Jun;23(6):301–13. PMID 23619509. Inadequate follow up time23619509
Musicco M. Lifestyle and rate of progression of cognitive decline: Results of the SINDEM cohort study. Journal of Alzheimer’s Disease. 2011;23(SUPPL. 1):S17–S8. PMID 2011121429. Not cognitive decline prevention intervention
Musicco M, Adorni F, Di Santo S, . Inverse occurrence of cancer and Alzheimer disease: A population-based incidence study. Neurology. 2013 23 Jul;81(4):322–8. PMID 2013498921. Not cognitive decline prevention intervention23843468
Na HR, Kim S, Choi SH, . Donepezil treatment in Alzheimer’s disease patients with and without cerebrovascular lesions: a preliminary report. Geriatrics & gerontology international. 2011 Jan;11(1):90–7. PMID 20825496. Ineligible population20825496
Nagata K, Yokoyama E, Yamazaki T, . Effects of yokukansan on behavioral and psychological symptoms of vascular dementia: an open-label trial. Phytomedicine. 2012 Apr 15;19(6):524–8. PMID 22421528. Ineligible population22421528
Naismith SL, Diamond K, Carter PE, . Enhancing memory in late-life depression: the effects of a combined psychoeducation and cognitive training program. American Journal of Geriatric Psychiatry. 2011 Mar;19(3):240–8. PMID 20808114. Inadequate follow up time20808114
Naismith SL, Glozier N, Burke D, . Early intervention for cognitive decline: is there a role for multiple medical or behavioural interventions? Early intervention in psychiatry. 2009 Feb;3(1):19–27. PMID 21352171. Ineligible study design21352171
Nakamura Y, Kitamura S, Homma A, . Efficacy and safety of memantine in patients with moderate-to-severe Alzheimer’s disease: results of a pooled analysis of two randomized, double-blind, placebo-controlled trials in Japan. Expert Opinion on Pharmacotherapy. 2014 May;15(7):913–25. PMID 24673497. Ineligible population24673497
Napryeyenko O, Sonnik G, Tartakovsky I. Efficacy and tolerability of Ginkgo biloba extract EGb 761 by type of dementia: analyses of a randomised controlled trial. Journal of the Neurological Sciences. 2009 Aug 15;283(1–2):224–9. PMID 19286192. Ineligible population19286192
Naqvi R, Liberman D, Rosenberg J, . Preventing cognitive decline in healthy older adults. CMAJ Canadian Medical Association Journal. 2013 Jul 9;185(10):881–5. PMID 23589432. Ineligible study design23589432
Narasimhalu K, Effendy S, Sim CH, . A randomized controlled trial of rivastigmine in patients with cognitive impairment no dementia because of cerebrovascular disease. Acta Neurologica Scandinavica. 2010 Apr;121(4):217–24. PMID 19951274. Ineligible population19951274
Nardone R, Tezzon F, Holler Y, . Transcranial magnetic stimulation (TMS)/repetitive TMS in mild cognitive impairment and Alzheimer’s disease. Acta Neurologica Scandinavica. 2014 Jun;129(6):351–66. PMID 24506061. Ineligible study design24506061
Narendran R, Frankle WG, Mason NS, . Improved working memory but no effect on striatal vesicular monoamine transporter type 2 after omega-3 polyunsaturated fatty acid supplementation. PLoS ONE [Electronic Resource]. 2012;7(10):e46832. PMID 23056476. No relevant outcomes reported23056476
Nasab NM, Bahrammi MA, Nikpour MR, . Efficacy of rivastigmine in comparison to ginkgo for treating Alzheimer’s dementia. JPMA - Journal of the Pakistan Medical Association. 2012 Jul;62(7):677–80. PMID 23866514. Ineligible population23866514
Nascimento CM, Teixeira CV, Gobbi LT, . A controlled clinical trial on the effects of exercise on neuropsychiatric disorders and instrumental activities in women with Alzheimer’s disease. Revista Brasileira de Fisioterapia. 2012 Jun;16(3):197–204. PMID 22499405. Ineligible population22499405
Nathan PJ, Watson J, Lund J, . The potent M1 receptor allosteric agonist GSK1034702 improves episodic memory in humans in the nicotine abstinence model of cognitive dysfunction. International Journal of Neuropsychopharmacology. 2013 May;16(4):721–31. PMID 22932339. Inadequate follow up time22932339
Nelson C, Wengreen HJ, Munger RG, . Dietary folate, vitamin B-12, vitamin B-6 and incident Alzheimer’s disease: the cache county memory, health and aging study. Journal of Nutrition, Health & Aging. 2009 Dec;13(10):899–905. PMID 19924351. Not cognitive decline prevention intervention19924351
Newhouse P, Albert K, Astur R, . Tamoxifen improves cholinergically modulated cognitive performance in postmenopausal women. Neuropsychopharmacology. 2013 Dec;38(13):2632–43. PMID 23867982. Inadequate follow up time23867982
Newhouse PA, Dumas J, Wilkins H, . Estrogen treatment impairs cognitive performance after psychosocial stress and monoamine depletion in postmenopausal women. Menopause. 2010 Jul;17(4):860–73. PMID 20616673. Inadequate follow up time20616673
Neznamov GG, Teleshova ES. Comparative studies of Noopept and piracetam in the treatment of patients with mild cognitive disorders in organic brain diseases of vascular and traumatic origin. Neuroscience & Behavioral Physiology. 2009 Mar;39(3):311–21. PMID 19234797. Inadequate follow up time19234797
Ng TP, Feng L, Yap KB, . Long-term metformin usage and cognitive function among older adults with diabetes. Journal of Alzheimer’s Disease. 2014;41(1):61–8. PMID 24577463. Cohort study with inadequate sample size24577463
Ngandu T, Lehtisalo J, Levalahti E, . Recruitment and baseline characteristics of participants in the finnish geriatric intervention study to prevent cognitive impairment and disability (FINGER)-A randomized controlled lifestyle trial. International Journal of Environmental Research and Public Health. 2014 10 Sep;11(9):9345–60. PMID 2014842635. Ineligible population25211775
Nho K, Kim S, Risacher SL, . Protective variant for hippocampal atrophy identified by whole exome sequencing. Annals of Neurology. 2015 Mar;77(3):547–52. PMID 2015-07189-001. Not cognitive decline prevention intervention25559091
Nilsson A, Radeborg K, Salo I, . Effects of supplementation with n-3 polyunsaturated fatty acids on cognitive performance and cardiometabolic risk markers in healthy 51 to 72 years old subjects: a randomized controlled cross-over study. Nutrition Journal. 2012;11:99. PMID 23173831. Inadequate follow up time23173831
Nishiguchi S, Yamada M, Tanigawa T, . A 12-Week Physical and Cognitive Exercise Program Can Improve Cognitive Function and Neural Efficiency in Community-Dwelling Older Adults: A Randomized Controlled Trial. Journal of the American Geriatrics Society. 2015 Jul;63(7):1355–63. PMID 26114906. Inadequate follow up time26114906
Noguchi-Shinohara M, Yuki S, Dohmoto C, . Consumption of green tea, but not black tea or coffee, is associated with reduced risk of cognitive decline. PLoS ONE. 2014 14 May;9(5)PMID 2014356288. Cohort study with inadequate sample size
Nolan JM, Loskutova E, Howard A, . The impact of supplemental macular carotenoids in Alzheimer’s disease: a randomized clinical trial. Journal of Alzheimer’s Disease. 2015;44(4):1157–69. PMID 25408222. Ineligible population25408222
Nordberg A, Kadir A, Andreasen N, . Correlations between Alzheimer’s Disease Cerebrospinal Fluid Biomarkers and Cerebral Glucose Metabolism after 12 Months of Phenserine Treatment. Journal of Alzheimer’s Disease. 2015 03 Aug;47(3):691–704. PMID 2015255626. Ineligible population
Norton MC, Clark CJ, Tschanz JT, . The design and progress of a multidomain lifestyle intervention to improve brain health in middle-aged persons to reduce later Alzheimer’s disease risk: The Gray Matters randomized trial. Alzheimer’s and Dementia: Translational Research and Clinical Interventions. 2015 14 Oct;1(1):53–62. PMID 2015440968. Ineligible study design
Norton MC, Dew J, Smith H, . Lifestyle behavior pattern is associated with different levels of risk for incident dementia and Alzheimer’s disease: the Cache County study. Journal of the American Geriatrics Society. 2012 Mar;60(3):405–12. PMID 22316091. Not cognitive decline prevention intervention22316091
Nouchi R, Taki Y, Takeuchi H, . Brain training game improves executive functions and processing speed in the elderly: a randomized controlled trial. PLoS ONE [Electronic Resource]. 2012;7(1):e29676. PMID 22253758. Inadequate follow up time22253758
Nouchi R, Taki Y, Takeuchi H, . Four weeks of combination exercise training improved executive functions, episodic memory, and processing speed in healthy elderly people: evidence from a randomized controlled trial. Age. 2014 Apr;36(2):787–99. PMID 24065294. Inadequate follow up time24065294
Novak V, Milberg W, Hao Y, . Enhancement of vasoreactivity and cognition by intranasal insulin in type 2 diabetes. Diabetes Care. 2014;37(3):751–9. PMID 24101698. Inadequate follow up time24101698
Nozawa M, Ichimiya Y, Nozawa E, . Clinical effects of high oral dose of donepezil for patients with Alzheimer’s disease in Japan. Psychogeriatrics:The Official Journal of the Japanese Psychogeriatric Society. 2009 Jun;9(2):50–5. PMID 19604325. Ineligible population19604325
Nunes MA, Viel TA, Buck HS. Microdose lithium treatment stabilized cognitive impairment in patients with Alzheimer’s disease. Current Alzheimer Research. 2013;10(1):104–7. PMID 2013746091. Ineligible population22746245
O’Callaghan N, Parletta N, Milte CM, . Telomere shortening in elderly individuals with mild cognitive impairment may be attenuated with omega-3 fatty acid supplementation: a randomized controlled pilot study. Nutrition. 2014 Apr;30(4):489–91. PMID 24342530. No relevant outcomes reported24342530
Oehlrich D, Berthelot DJ, Gijsen HJ. gamma-Secretase modulators as potential disease modifying anti-Alzheimer’s drugs. Journal of Medicinal Chemistry. 2011 Feb 10;54(3):669–98. PMID 21141968. Ineligible study design21141968
Oei NY, Tollenaar MS, Elzinga BM, . Propranolol reduces emotional distraction in working memory: a partial mediating role of propranolol-induced cortisol increases? Neurobiology of Learning & Memory. 2010 Mar;93(3):388–95. PMID 20018249. Inadequate follow up time20018249
Ogunniyi A, Gao S, Unverzagt FW, . Weight loss and incident dementia in elderly Yoruba Nigerians: a 10-year follow-up study. International Psychogeriatrics. 2011 Apr;23(3):387–94. PMID 20735893. Ineligible population20735893
Ohara T, Ninomiya T, Kubo M, . Apolipoprotein genotype for prediction of Alzheimer’s disease in older Japanese: the Hisayama Study. Journal of the American Geriatrics Society. 2011 Jun;59(6):1074–9. PMID 21649613. Not cognitive decline prevention intervention21649613
O’Hare AM, Walker R, Haneuse S, . Relationship between longitudinal measures of renal function and onset of dementia in a community cohort of older adults. Journal of the American Geriatrics Society. 2012 December;60(12):2215–22. PMID 2012730823. Not cognitive decline prevention intervention23231548
Ohnishi T, Sakiyama Y, Okuri Y, . The prediction of response to galantamine treatment in patients with mild to moderate Alzheimer’s disease. Current Alzheimer Research. 2014 Feb;11(2):110–8. PMID 24156269. Ineligible population24156269
Okereke OI, Kurth T, Pollak MN, . Fasting plasma insulin, C-peptide and cognitive change in older men without diabetes: results from the Physicians’ Health Study II. Neuroepidemiology. 2010;34(4):200–7. PMID 20197703. Not cognitive decline prevention intervention20197703
Okereke OI, Rosner BA, Kim DH, . Dietary fat types and 4-year cognitive change in community-dwelling older women.[Erratum appears in Ann Neurol. 2012 Oct;72(4):627]. Annals of Neurology. 2012 Jul;72(1):124–34. PMID 22605573. Ineligible study design22605573
Okonkwo OC, Schultz SA, Oh JM, . Physical activity attenuates age-related biomarker alterations in preclinical AD. Neurology. 2014 04 Nov;83(19):1753–60. PMID 25298312. Cohort study with inadequate sample size25298312
Okonkwo OC, Xu G, Dowling NM, . Family history of Alzheimer disease predicts hippocampal atrophy in healthy middle-aged adults. Neurology. 2012 May 29;78(22):1769–76. PMID 22592366. Not cognitive decline prevention intervention22592366
Olchik MR, Farina J, Steibel N, . Memory training (MT) in mild cognitive impairment (MCI) generates change in cognitive performance. Archives of Gerontology & Geriatrics. 2013 May–Jun;56(3):442–7. PMID 23260332. Inadequate follow up time23260332
Olde Rikkert MG, Verhey FR, Blesa R, . Tolerability and safety of Souvenaid in patients with mild Alzheimer’s disease: results of multi-center, 24-week, open-label extension study. Journal of Alzheimer’s Disease. 2015;44(2):471–80. PMID 25322923. Ineligible population25322923
Olde Rikkert MG, Verhey FR, Sijben JW, . Differences in nutritional status between very mild Alzheimer’s disease patients and healthy controls. Journal of Alzheimer’s Disease. 2014;41(1):261–71. PMID 24614903. Not cognitive decline prevention intervention24614903
Olin JT, Bhatnagar V, Reyes P, . Safety and tolerability of rivastigmine capsule with memantine in patients with probable Alzheimer’s disease: a 26-week, open-label, prospective trial (Study ENA713B US32). International Journal of Geriatric Psychiatry. 2010 Apr;25(4):419–26. PMID 19670390. Ineligible population19670390
Onur OA, Schlaepfer TE, Kukolja J, . The N-Methyl-D-Aspartate Receptor Co-agonist D-Cycloserine Facilitates Declarative Learning and Hippocampal Activity in Humans. Biological Psychiatry. 2010 15 Jun;67(12):1205–11. PMID 2010302403. Inadequate follow up time20303474
Optale G, Urgesi C, Busato V, . Controlling memory impairment in elderly adults using virtual reality memory training: a randomized controlled pilot study. Neurorehabilitation & Neural Repair. 2010 May;24(4):348–57. PMID 19934445. Ineligible population19934445
Orgeta V, Leung P, Yates L, . Individual cognitive stimulation therapy for dementia: A clinical effectiveness and cost-effectiveness pragmatic, multicentre, randomised controlled trial. Health Technology Assessment. 2015 01 Aug;19(64):7–73. PMID 2015323100. Ineligible population
Ormstad H, Rosness TA, Bergem ALM, . Alcohol consumption in the elderly and risk of dementia related death - A Norwegian prospective study with a 17-year follow-up. International Journal of Neuroscience. 2016 01 Feb;126(2):135–44. PMID 2015246336. No relevant outcomes reported25495993
Orrell M, Aguirre E, Spector A, . Maintenance cognitive stimulation therapy for dementia: single-blind, multicentre, pragmatic randomised controlled trial. British Journal of Psychiatry. 2014 Jun;204(6):454–61. PMID 24676963. Ineligible population24676963
Ostrowitzki S, Deptula D, Thurfjell L, . Mechanism of amyloid removal in patients with Alzheimer disease treated with gantenerumab. Archives of Neurology. 2012 Feb;69(2):198–207. PMID 21987394. Ineligible population21987394
Otilingam PG, Gatz M, Tello E, . Buenos habitos alimenticios para una buena salud : evaluation of a nutrition education program to improve heart health and brain health in Latinas. Journal of Aging & Health. 2015 Feb;27(1):177–92. PMID 25231884. Inadequate follow up time25231884
Owen AM, Hampshire A, Grahn JA, . Putting brain training to the test. Nature. 2010 Jun 10;465(7299):775–8. PMID 20407435. Inadequate follow up time20407435
Owen L, Scholey A, Finnegan Y, . Response variability to glucose facilitation of cognitive enhancement. British Journal of Nutrition. 2013 Nov;110(10):1873–84. PMID 23789911. Inadequate follow up time23789911
Ozawa M, Ninomiya T, Ohara T, . Dietary patterns and risk of dementia in an elderly Japanese population: the Hisayama Study. American Journal of Clinical Nutrition. 2013 May;97(5):1076–82. PMID 23553168. Not cognitive decline prevention intervention23553168
Ozawa M, Ninomiya T, Ohara T, . Self-reported dietary intake of potassium, calcium, and magnesium and risk of dementia in the Japanese: the Hisayama Study. Journal of the American Geriatrics Society. 2012 Aug;60(8):1515–20. PMID 22860881. Not cognitive decline prevention intervention22860881
Ozawa M, Ohara T, Ninomiya T, . Milk and dairy consumption and risk of dementia in an elderly Japanese population: the Hisayama Study. Journal of the American Geriatrics Society. 2014 Jul;62(7):1224–30. PMID 24916840. Not cognitive decline prevention intervention24916840
Packard CJ, Westendorp RG, Stott DJ, . Association between apolipoprotein E4 and cognitive decline in elderly adults. Journal of the American Geriatrics Society. 2007 Nov;55(11):1777–85. PMID 17979899. Not cognitive decline prevention intervention17979899
Paganini-Hill A. Hypertension and dementia in the elderly: The leisure world cohort study. International Journal of Hypertension. 2012;2012 (no pagination)(205350)PMID 2012644430. Not cognitive decline prevention intervention
Paganini-Hill A, White SC, Atchison KA. Dentition, dental health habits, and dementia: the Leisure World Cohort Study. Journal of the American Geriatrics Society. 2012 Aug;60(8):1556–63. PMID 22860988. Not cognitive decline prevention intervention22860988
Page KA, Williamson A, Yu N, . Medium-chain fatty acids improve cognitive function in intensively treated type 1 diabetic patients and support in vitro synaptic transmission during acute hypoglycemia. Diabetes. 2009 May;58(5):1237–44. PMID 19223595. Inadequate follow up time19223595
Pai MC, Aref H, Bassil N, . Real-world evaluation of compliance and preference in Alzheimer’s disease treatment. Clinical Interventions in Aging. 2015 03 Nov;10:1779–88. PMID 2015508490. No relevant outcomes reported26622172
Paillard-Borg S, Fratiglioni L, Xu W, . An active lifestyle postpones dementia onset by more than one year in very old adults. Journal of Alzheimer’s Disease. 2012;31(4):835–42. PMID 22751170. Not cognitive decline prevention intervention22751170
Pakdaman H, Harandi AA, Hatamian H, . Effectiveness and safety of MLC601 in the treatment of mild to moderate Alzheimer’s disease: A multicenter, randomized controlled trial. Dementia and Geriatric Cognitive Disorders Extra. 2015;5(1):96–106. PMID 2015140253. Ineligible population25873931
Palinkas LA, Reedy KR, Shepanek M, . A randomized placebo-controlled clinical trial of the effectiveness of thyroxine and triiodothyronine and short-term exposure to bright light in prevention of decrements in cognitive performance and mood during prolonged Antarctic residence. Clinical Endocrinology. 2010 Apr;72(4):543–50. PMID 19650782. Inadequate follow up time19650782
Panza F, Frisardi V, Seripa D, . Alcohol consumption in mild cognitive impairment and dementia: harmful or neuroprotective? International Journal of Geriatric Psychiatry. 2012 Dec;27(12):1218–38. PMID 22396249. Ineligible study design22396249
Panza F, Solfrizzi V, Barulli MR, . Coffee, tea, and caffeine consumption and prevention of late-life cognitive decline and dementia: a systematic review. Journal of Nutrition, Health & Aging. 2015 Mar;19(3):313–28. PMID 25732217. Ineligible study design25732217
Parikh NM, Morgan RO, Kunik ME, . Risk factors for dementia in patients over 65 with diabetes. International Journal of Geriatric Psychiatry. 2011 July;26(7):749–57. PMID 2011213017. Not cognitive decline prevention intervention20891020
Park SH, Seo JH, Kim YH, . Long-term effects of transcranial direct current stimulation combined with computer-assisted cognitive training in healthy older adults. Neuroreport. 2014 Jan 22;25(2):122–6. PMID 24176927. Inadequate follow up time24176927
Park SK, Jung IC, Lee WK, . A combination of green tea extract and l-theanine improves memory and attention in subjects with mild cognitive impairment: a double-blind placebo-controlled study. Journal of Medicinal Food. 2011 Apr;14(4):334–43. PMID 21303262. Inadequate follow up time21303262
Parnetti L, Chiasserini D, Andreasson U, . Changes in CSF acetyl- and butyrylcholinesterase activity after long-term treatment with AChE inhibitors in Alzheimer’s disease. Acta Neurologica Scandinavica. 2011 Aug;124(2):122–9. PMID 20880294. Ineligible population20880294
Pasqualetti P, Bonomini C, Dal Forno G, . A randomized controlled study on effects of ibuprofen on cognitive progression of Alzheimer’s disease. Aging-Clinical & Experimental Research. 2009 Apr;21(2):102–10. PMID 19448381. Ineligible population19448381
Patat A, Parks V, Raje S, . Safety, tolerability, pharmacokinetics and pharmacodynamics of ascending single and multiple doses of lecozotan in healthy young and elderly subjects. British Journal of Clinical Pharmacology. 2009 Mar;67(3):299–308. PMID 19523013. Inadequate follow up time19523013
Pathan SS, Gottesman RF, Mosley TH, . Association of lung function with cognitive decline and dementia: the Atherosclerosis Risk in Communities (ARIC) Study. European Journal of Neurology. 2011 Jun;18(6):888–98. PMID 21244584. Not cognitive decline prevention intervention21244584
Peneau S, Galan P, Jeandel C, . Fruit and vegetable intake and cognitive function in the SU.VI.MAX 2 prospective study. American Journal of Clinical Nutrition. 2011 Nov;94(5):1295–303. PMID 21955649. No relevant outcomes reported21955649
Peng J, Lu F, Wang Z, . Excessive lowering of blood pressure is not beneficial for progression of brain white matter hyperintensive and cognitive impairment in elderly hypertensive patients: 4-year follow-up study. Journal of the American Medical Directors Association. 2014 Dec;15(12):904–10. PMID 25239015. Cohort study with inadequate sample size25239015
Peng YH, Wu BR, Su CH, . Adult asthma increases dementia risk: a nationwide cohort study. Journal of Epidemiology & Community Health. 2015 Feb;69(2):123–8. PMID 25271249. Not cognitive decline prevention intervention25271249
Pengelly A, Snow J, Mills SY, . Short-term study on the effects of rosemary on cognitive function in an elderly population. Journal of Medicinal Food. 2012 Jan;15(1):10–7. PMID 21877951. Inadequate follow up time21877951
Peretz C, Korczyn AD, Shatil E, . Computer-based, personalized cognitive training versus classical computer games: a randomized double-blind prospective trial of cognitive stimulation. Neuroepidemiology. 2011;36(2):91–9. PMID 21311196. Inadequate follow up time21311196
Perez L, Heim L, Sherzai A, . Nutrition and vascular dementia. Journal of Nutrition, Health & Aging. 2012 Apr;16(4):319–24. PMID 22499449. Ineligible study design22499449
Perkins KA, Karelitz JL, Jao NC, . Effects of bupropion on cognitive performance during initial tobacco abstinence. Drug & Alcohol Dependence. 2013 Nov 1;133(1):283–6. PMID 23726977. Inadequate follow up time23726977
Persson CM, Wallin AK, Levander S, . Changes in cognitive domains during three years in patients with Alzheimer’s disease treated with donepezil. BMC Neurology. 2009;9:7. PMID 19208247. Ineligible population19208247
Persson N, Viitanen M, Almkvist O, . A principal component model of medical health: implications for cognitive deficits and decline among adults in a population-based sample. Journal of Health Psychology. 2013 Oct;18(10):1268–87. PMID 23180878. Ineligible study design23180878
Peters O. [Alzheimer’s disease: are non-steroidal anti-inflammatory drugs effective?]. Deutsche Medizinische Wochenschrift. 2012 Dec;137(50):2627. PMID 23225182. Not available in English23225182
Peters R, Beckett N, Fagard R, . Increased pulse pressure linked to dementia: further results from the Hypertension in the Very Elderly Trial - HYVET. Journal of Hypertension. 2013 Sep;31(9):1868–75. PMID 23743809. Ineligible study design23743809
Phung KTT, Waldorff FB, Buss DV, . A three-year follow-up on the efficacy of psychosocial interventions for patients with mild dementia and their caregivers: The multicentre, rater-blinded, randomised Danish Alzheimer Intervention Study (DAISY). BMJ Open. 2013;3(11)PMID 2013772352. Ineligible population
Pietrzak RH, Lim YY, Ames D, . Trajectories of memory decline in preclinical Alzheimer’s disease: results from the Australian Imaging, Biomarkers and Lifestyle Flagship Study of ageing. Neurobiology of Aging. 2015 Mar;36(3):1231–8. PMID 25585532. Not cognitive decline prevention intervention25585532
Piette F, Belmin J, Vincent H, . Masitinib as an adjunct therapy for mild-to-moderate Alzheimer’s disease: A randomised, placebo-controlled phase 2 trial. Alzheimer’s Research and Therapy. 2011;3(2)PMID 2011300018. Ineligible population
Pilatus U, Lais C, Rochmont Adu M, . Conversion to dementia in mild cognitive impairment is associated with decline of N-actylaspartate and creatine as revealed by magnetic resonance spectroscopy. Psychiatry Research. 2009 Jul 15;173(1):1–7. PMID 19427767. Cohort study with inadequate sample size19427767
Pitkala KH, Poysti MM, Laakkonen ML, . Effects of the Finnish Alzheimer disease exercise trial (FINALEX): a randomized controlled trial. JAMA Internal Medicine. 2013 May 27;173(10):894–901. PMID 23589097. Ineligible population23589097
Pitkala KH, Raivio MM, Laakkonen ML, . Exercise rehabilitation on home-dwelling patients with Alzheimer disease: A randomized, controlled trial. Baseline findings and feasibility. European Geriatric Medicine. 2011 December;2(6):338–43. PMID 2011616075. Ineligible population
Pitkala KH, Routasalo P, Kautiainen H, . Effects of socially stimulating group intervention on lonely, older people’s cognition: a randomized, controlled trial. American Journal of Geriatric Psychiatry. 2011 Jul;19(7):654–63. PMID 21709611. Ineligible population21709611
Plassman BL, Williams JW, Jr., Burke JR, . Systematic review: factors associated with risk for and possible prevention of cognitive decline in later life. Annals of Internal Medicine. 2010 Aug 3;153(3):182–93. PMID 20547887. Ineligible study design20547887
Plastino M, Fava A, Pirritano D, . Effects of insulinic therapy on cognitive impairment in patients with Alzheimer disease and diabetes mellitus type-2. Journal of the Neurological Sciences. 2010 Jan 15;288(1–2):112–6. PMID 19836029. Ineligible population19836029
Polito L, Abbondanza S, Vaccaro R, . Cognitive stimulation in cognitively impaired individuals and cognitively healthy individuals with a family history of dementia: Short-term results from the “allena-Mente” randomized controlled trial. International Journal of Geriatric Psychiatry. 2015 01 Jun;30(6):631–8. PMID 2015029633. Inadequate follow up time25187003
Poly C, Massaro JM, Seshadri S, . The relation of dietary choline to cognitive performance and white-matter hyperintensity in the Framingham Offspring Cohort. American Journal of Clinical Nutrition. 2011 Dec;94(6):1584–91. PMID 22071706. No relevant outcomes reported22071706
Popa MA, Reynolds SL, Small BJ. Is the effect of reported physical activity on disability mediated by cognitive performance in white and african american older adults? Journals of Gerontology Series B-Psychological Sciences & Social Sciences. 2009 Jan;64(1):4–13. PMID 19196688. No relevant outcomes reported19196688
Postuma RB, Gagnon JF, Vendette M, . Idiopathic REM sleep behavior disorder in the transition to degenerative disease. Movement Disorders. 2009 Nov 15;24(15):2225–32. PMID 19768814. Cohort study with inadequate sample size19768814
Potter AS, Ryan KK, Newhouse PA. Effects of acute ultra-low dose mecamylamine on cognition in adult attention-deficit/hyperactivity disorder (ADHD). Human Psychopharmacology. 2009 Jun;24(4):309–17. PMID 19475630. Inadequate follow up time19475630
Power BD, Alfonso H, Flicker L, . Body adiposity in later life and the incidence of dementia: The health in men study. PLoS ONE. 2011;6 (3) (no pagination)(e17902)PMID 2011168273. Not cognitive decline prevention intervention
Pratt SI, Mueser KT, Bartels SJ, . The impact of skills training on cognitive functioning in older people with serious mental illness. American Journal of Geriatric Psychiatry. 2013 Mar;21(3):242–50. PMID 23395191. Ineligible population23395191
Pregelj P. Safety and tolerability of rivastigmine transdermal patch formulation in newly diagnosed patients with Alzheimer’s dementia in naturalistic conditions. Psychogeriatrics:The Official Journal of the Japanese Psychogeriatric Society. 2012 Sep;12(3):165–71. PMID 22994614. Ineligible population22994614
Pressman P, Gottfried JA. Journal Club: A randomized, double-blind, placebo-controlled trial of simvastatin to treat Alzheimer disease. Neurology. 2012 24 Jul;79(4):e33–e6. PMID 2012534317. Ineligible population22826548
Pribis P, Bailey RN, Russell AA, . Effects of walnut consumption on cognitive performance in young adults. British Journal of Nutrition. 2012 May;107(9):1393–401. PMID 21923981. Inadequate follow up time21923981
Puustinen J, Nurminen J, Lopponen M, . Use of CNS medications and cognitive decline in the aged: a longitudinal population-based study. BMC Geriatrics. 2011;11:70. PMID 22044595. No relevant outcomes reported22044595
Qin B, Adair LS, Plassman BL, . Dietary Patterns and Cognitive Decline among Chinese Older Adults. Epidemiology. 2015 25 Sep;26(5):758–68. PMID 2015328540. Ineligible study design26133024
Qin B, Plassman BL, Edwards LJ, . Fish intake is associated with slower cognitive decline in Chinese older adults. Journal of Nutrition. 2014 Oct;144(10):1579–85. PMID 25080536. Ineligible study design25080536
Qiu C, Winblad B, Fratiglioni L. Low diastolic pressure and risk of dementia in very old people: a longitudinal study. Dementia & Geriatric Cognitive Disorders. 2009;28(3):213–9. PMID 19752556. Cohort study with inadequate sample size19752556
Quinn JF, Raman R, Thomas RG, . Docosahexaenoic acid supplementation and cognitive decline in Alzheimer disease: a randomized trial. JAMA. 2010 Nov 3;304(17):1903–11. PMID 21045096. Ineligible population21045096
Raabe RD, Burr RB, Short R. One-year cognitive outcomes associated with carotid artery stent placement. Journal of Vascular & Interventional Radiology. 2010 Jul;21(7):983–8; quiz 9. PMID 20537561. Ineligible study design20537561
Radaideh GA, Choueiry P, Ismail A, . Eprosartan-based hypertension therapy, systolic arterial blood pressure and cognitive function: analysis of Middle East data from the OSCAR study. Vascular Health & Risk Management. 2011;7:491–5. PMID 21915165. Cohort study with inadequate sample size21915165
Rahe J, Liesk J, Rosen JB, . Sex differences in cognitive training effects of patients with amnestic mild cognitive impairment. Aging, Neuropsychology, and Cognition. 2015 Sep;22(5):620–38. PMID 2015-26603-007. Ineligible study design
Rahe J, Petrelli A, Kaesberg S, . Effects of cognitive training with additional physical activity compared to pure cognitive training in healthy older adults. Clinical Interventions In Aging. 2015;10:297–310. PMID 25632227. Cohort study with inadequate sample size25632227
Rainer M, Wuschitz A, Jagsch C, . Memantine in moderate to severe Alzheimer’s disease: an observational post-marketing study. Journal of Neural Transmission. 2011 Aug;118(8):1255–9. PMID 21461744. Cohort study with inadequate sample size21461744
Ramirez A, Wolfsgruber S, Lange C, . Elevated HbA1c is associated with increased risk of incident dementia in primary care patients. Journal of Alzheimer’s Disease. 2015;44(4):1203–12. PMID 25524954. Ineligible study design25524954
Rantanen KK, Strandberg AY, Pitkala K, . Cholesterol in midlife increases the risk of Alzheimer’s disease during an up to 43-year follow-up. European Geriatric Medicine. 2014 01 Dec;5(6):390–3. PMID 2015641416. Ineligible study design
Ravona-Springer R, Beeri MS, Goldbourt U. Repetitive thinking as a psychological cognitive style in midlife is associated with lower risk for dementia three decades later. Dementia & Geriatric Cognitive Disorders. 2009;28(6):513–20. PMID 19996596. Ineligible study design19996596
Ravona-Springer R, Beeri MS, Goldbourt U. Exposure to the Holocaust and World War II concentration camps during late adolescence and adulthood is not associated with increased risk for dementia at old age. Journal of Alzheimer’s Disease. 2011;23(4):709–16. PMID 21157030. Ineligible study design21157030
Ravona-Springer R, Beeri MS, Goldbourt U. Satisfaction with current status at work and lack of motivation to improve it during midlife is associated with increased risk for dementia in subjects who survived thirty-seven years later. Journal of Alzheimer’s Disease. 2013;36(4):769–80. PMID 23703153. Ineligible study design23703153
Razay G, Williams J, King E, . Blood pressure, dementia and Alzheimer’s disease: the OPTIMA longitudinal study. Dementia & Geriatric Cognitive Disorders. 2009;28(1):70–4. PMID 19648748. Cohort study with inadequate sample size19648748
Redick TS, Shipstead Z, Harrison TL, . No evidence of intelligence improvement after working memory training: a randomized, placebo-controlled study. Journal of Experimental Psychology: General. 2013 May;142(2):359–79. PMID 22708717. Inadequate follow up time22708717
Reiner M, Niermann C, Jekauc D, . Long-term health benefits of physical activity--a systematic review of longitudinal studies. BMC Public Health. 2013;13:813. PMID 24010994. Ineligible study design24010994
Reitz C, Tang MX, Miller J, . Plasma homocysteine and risk of mild cognitive impairment. Dementia and Geriatric Cognitive Disorders. 2009 February;27(1):11–7. PMID 2009076033. Ineligible study design19088473
Reitz C, Tang MX, Schupf N, . Association of higher levels of high-density lipoprotein cholesterol in elderly individuals and lower risk of late-onset Alzheimer disease. Archives of Neurology. 2010 Dec;67(12):1491–7. PMID 21149810. Ineligible population21149810
Relkin NR, Szabo P, Adamiak B, . 18-Month study of intravenous immunoglobulin for treatment of mild Alzheimer disease. Neurobiology of Aging. 2009 November;30(11):1728–36. PMID 2009480127. Ineligible population18294736
Remington R, Bechtel C, Larsen D, . A Phase II Randomized Clinical Trial of a Nutritional Formulation for Cognition and Mood in Alzheimer’s Disease. Journal of Alzheimer’s Disease. 2015;45(2):395–405. PMID 2015856032. Ineligible population
Remington R, Chan A, Paskavitz J, . Efficacy of a vitamin/nutriceutical formulation for moderate-stage to later-stage Alzheimer’s disease: a placebo-controlled pilot study. American Journal of Alzheimer’s Disease & Other Dementias. 2009 Feb–Mar;24(1):27–33. PMID 19056706. Ineligible population19056706
Reppermund S, Brodaty H, Crawford JD, . Impairment in instrumental activities of daily living with high cognitive demand is an early marker of mild cognitive impairment: the Sydney memory and ageing study. Psychological Medicine. 2013 Nov;43(11):2437–45. PMID 23308393. Ineligible study design23308393
Ribeiro Salomon AL, Carvalho Garbi Novaes MR. Outcomes of enteral nutrition for patients with advanced dementia - A systematic review. Journal of Nutrition, Health and Aging. 2015;19(2):169–77. PMID 2014834627. Ineligible population
Ribeiro Salomon AL, Carvalho Garbi Novaes MR. Outcomes of enteral nutrition for patients with advanced dementia: a systematic review. Journal of Nutrition, Health & Aging. 2015 Feb;19(2):169–77. PMID 25651442. Ineligible population25651442
Richard E, Gouw AA, Scheltens P, . Vascular care in patients with Alzheimer disease with cerebrovascular lesions slows progression of white matter lesions on MRI: The evaluation of vascular care in Alzheimer’s disease (EVA) study. Stroke. 2010 March;41(3):554–6. PMID 2010142301. Ineligible population20056923
Richard E, Jongstra S, Soininen H, . Healthy Ageing Through Internet Counselling in the Elderly: The HATICE randomised controlled trial for the prevention of cardiovascular disease and cognitive impairment. BMJ Open. 2016 01 Jun;6(6) (no pagination)(987)PMID 610788580. Ineligible study design
Richard E, Kuiper R, Dijkgraaf MG, . Vascular care in patients with Alzheimer’s disease with cerebrovascular lesions-a randomized clinical trial. Journal of the American Geriatrics Society. 2009 May;57(5):797–805. PMID 19484836. Ineligible population19484836
Richard E, Van den Heuvel E, Moll van Charante EP, . Prevention of dementia by intensive vascular care (PreDIVA): a cluster-randomized trial in progress. Alzheimer Disease & Associated Disorders. 2009 Jul–Sep;23(3):198–204. PMID 19812459. Inadequate follow up time19812459
Richardson K, Schoen M, French B, . Statins and cognitive function: a systematic review. Annals of Internal Medicine. 2013 Nov 19;159(10):688–97. PMID 24247674. Ineligible study design24247674
Richarz U, Gaudig M, Rettig K, . Galantamine treatment in outpatients with mild Alzheimer’s disease. Acta Neurologica Scandinavica. 2014 Jun;129(6):382–92. PMID 24461047. Ineligible population24461047
Richmond LL, Morrison AB, Chein JM, . Working memory training and transfer in older adults. Psychology & Aging. 2011 Dec;26(4):813–22. PMID 21707176. Inadequate follow up time21707176
Ridker PM, Danielson E, Fonseca FA, . Rosuvastatin to prevent vascular events in men and women with elevated C-reactive protein. New England Journal of Medicine. 2008 Nov 20;359(21):2195–207. PMID 18997196. No relevant outcomes reported18997196
Riepe M, Weinman J, Osae-Larbi J, . Factors Associated with Greater Adherence to and Satisfaction with Transdermal Rivastigmine in Patients with Alzheimer’s Disease and Their Caregivers. Dementia and Geriatric Cognitive Disorders. 2015 22 Jul;40(1–2):107–19. PMID 2015125853. Ineligible population26066776
Rijpma A, Meulenbroek O, Van Hees AMJ, . Effects of Souvenaid on plasma micronutrient levels and fatty acid profiles in mild and mild-to-moderate Alzheimer’s disease. Alzheimer’s Research and Therapy. 2015 24 Jul;7(1)PMID 2015224044. Ineligible population
Rinne JO, Brooks DJ, Rossor MN, . 11C-PiB PET assessment of change in fibrillar amyloid-beta load in patients with Alzheimer’s disease treated with bapineuzumab: a phase 2, double-blind, placebo-controlled, ascending-dose study. Lancet Neurology. 2010 Apr;9(4):363–72. PMID 20189881. Ineligible population20189881
Rist PM, Capistrant BD, Wu Q, . Dementia and dependence: do modifiable risk factors delay disability? Neurology. 2014 Apr 29;82(17):1543–50. PMID 24682970. Ineligible study design24682970
Ritchie K, Ancelin ML, Amieva H, . The association between caffeine and cognitive decline: examining alternative causal hypotheses. International Psychogeriatrics. 2014 Apr;26(4):581–90. PMID 24423697. Ineligible study design24423697
Ritchie K, Carriere I, Ritchie CW, . Designing prevention programmes to reduce incidence of dementia: prospective cohort study of modifiable risk factors. BMJ. 2010;341:c3885. PMID 20688841. Ineligible study design20688841
Ritchie LJ. Identifying mild cognitive impairment in older adults. Dissertation Abstracts International: Section B: The Sciences and Engineering. 2010;71(6-B):3945. PMID Dissertation Abstract: 2010-99240-330. Ineligible study design
Roberts RO, Geda YE, Cerhan JR, . Vegetables, unsaturated fats, moderate alcohol intake, and mild cognitive impairment. Dementia & Geriatric Cognitive Disorders. 2010;29(5):413–23. PMID 20502015. Ineligible study design20502015
Roberts RO, Geda YE, Knopman DS, . Cardiac disease associated with increased risk of nonamnestic cognitive impairment. JAMA Neurology. 2013 March;70(3):374–82. PMID 2013161568. Ineligible study design
Roberts RO, Roberts LA, Geda YE, . Relative intake of macronutrients impacts risk of mild cognitive impairment or dementia. Journal of Alzheimer’s Disease. 2012;32(2):329–39. PMID 22810099. Ineligible study design22810099
Rockwood K, Fay S, Gorman M. The ADAS-cog and clinically meaningful change in the VISTA clinical trial of galantamine for Alzheimer’s disease. International Journal of Geriatric Psychiatry. 2010 Feb;25(2):191–201. PMID 19548273. Ineligible population19548273
Rockwood K, Kirkland S, Hogan DB, . Use of lipid-lowering agents, indication bias, and the risk of dementia in community-dwelling elderly people. Archives of Neurology. 2002 Feb;59(2):223–7. PMID 11843693. Ineligible study design11843693
Rodriguez-Sanchez E, Criado-Gutierrez JM, Mora-Simon S, . Physical activity program for patients with dementia and their relative caregivers: randomized clinical trial in Primary Health Care (AFISDEMyF study). BMC Neurology. 2014;14:63. PMID 24684948. Ineligible population24684948
Rojas G, Bartoloni L, Serrano C, . Naturalist observational study on effectiveness of drug treatment of a cohort of patients with Alzheimer type dementia. [Spanish] Estudio observacional naturalistico sobre la efectividad del tratamiento farmacologico en una cohorte de pacientes con demencia tipo Alzheimer. Neurologia Argentina. 2010;2(1):21–8. PMID 2010675945. Ineligible population
Rondeau V, Jacqmin-Gadda H, Commenges D, . Aluminum and silica in drinking water and the risk of Alzheimer’s disease or cognitive decline: findings from 15-year follow-up of the PAQUID cohort. American Journal of Epidemiology. 2009 Feb 15;169(4):489–96. PMID 19064650. Ineligible study design19064650
Ronnemaa E, Zethelius B, Sundelof J, . Glucose metabolism and the risk of Alzheimer’s disease and dementia: a population-based 12 year follow-up study in 71-year-old men. Diabetologia. 2009 Aug;52(8):1504–10. PMID 19455303. Ineligible study design19455303
Ronnemaa E, Zethelius B, Vessby B, . Serum fatty-acid composition and the risk of Alzheimer’s disease: a longitudinal population-based study. European Journal of Clinical Nutrition. 2012 Aug;66(8):885–90. PMID 22713770. Ineligible study design22713770
Rosano C, Longstreth WT, Jr., Boudreau R, . High blood pressure accelerates gait slowing in well-functioning older adults over 18-years of follow-up. Journal of the American Geriatrics Society. 2011 Mar;59(3):390–7. PMID 21391929. No relevant outcomes reported21391929
Rosen AC, Sugiura L, Kramer JH, . Cognitive training changes hippocampal function in mild cognitive impairment: a pilot study. Journal of Alzheimer’s Disease. 2011;26 Suppl 3:349–57. PMID 21971474. Inadequate follow up time21971474
Rosenberg PB, Mielke MM, Han D, . The association of psychotropic medication use with the cognitive, functional, and neuropsychiatric trajectory of Alzheimer’s disease. International Journal of Geriatric Psychiatry. 2012 Dec;27(12):1248–57. PMID 22374884. Cohort study with inadequate sample size22374884
Rosenbloom MH, Barclay TR, Pyle M, . A single-dose pilot trial of intranasal rapid-acting insulin in apolipoprotein E4 carriers with mild-moderate Alzheimer’s disease. CNS Drugs. 2014 Dec;28(12):1185–9. PMID 25373630. Ineligible population25373630
Roth T, Richardson GR, Sullivan JP, . Comparative effects of pravastatin and lovastatin on nighttime sleep and daytime performance. Clinical Cardiology. 1992 Jun;15(6):426–32. PMID 1617822. Inadequate follow up time1617822
Rovner BW, Casten RJ, Leiby BE, . Activity loss is associated with cognitive decline in age-related macular degeneration. Alzheimer’s & Dementia. 2009 Jan;5(1):12–7. PMID 19118805. Cohort study with inadequate sample size19118805
Ruiz JR, Gil-Bea F, Bustamante-Ara N, . Resistance training does not have an effect on cognition or related serum biomarkers in nonagenarians: a randomized controlled trial. International Journal of Sports Medicine. 2015 Jan;36(1):54–60. PMID 25329433. Inadequate follow up time25329433
Ryan J, Carriere I, Carcaillon L, . Estrogen receptor polymorphisms and incident dementia: the prospective 3C study. Alzheimer’s & Dementia. 2014 Jan;10(1):27–35. PMID 23491264. Ineligible study design23491264
Ryan J, Carriere I, Scali J, . Characteristics of hormone therapy, cognitive function, and dementia: the prospective 3C Study. Neurology. 2009 Nov 24;73(21):1729–37. PMID 19933973. Ineligible population19933973
Ryberg C, Rostrup E, Paulson OB, . Corpus callosum atrophy as a predictor of age-related cognitive and motor impairment: a 3-year follow-up of the LADIS study cohort. Journal of the Neurological Sciences. 2011 Aug 15;307(1–2):100–5. PMID 21621224. Ineligible study design21621224
Sabbagh M, Cummings J, Christensen D, . Evaluating the cognitive effects of donepezil 23 mg/d in moderate and severe Alzheimer’s disease: analysis of effects of baseline features on treatment response. BMC Geriatrics. 2013;13:56. PMID 23742728. Ineligible population23742728
Sachs-Ericsson NJ, Sawyer KA, Corsentino EA, . APOE epsilon4 allele carriers: Biological, psychological, and social variables associated with cognitive impairment. Aging & Mental Health. 2010 Aug;14(6):679–91. PMID 20686979. Ineligible study design20686979
Sadhu A, Upadhyay P, Agrawal A, . Management of cognitive determinants in senile dementia of Alzheimer’s type: therapeutic potential of a novel polyherbal drug product. Clinical Drug Investigation. 2014 Dec;34(12):857–69. PMID 25316430. Ineligible population25316430
Sadowsky CH, Dengiz A, Meng X, . Switching from oral donepezil to rivastigmine transdermal patch in alzheimer’s disease: 20-week extension phase results. Primary Care Companion to the Journal of Clinical Psychiatry. 2010;12(5):e1–e8. PMID 2010710976. Ineligible population
Safouris A, Tsivgoulis G, Sergentanis TN, . Mediterranean diet and risk of dementia. Current Alzheimer Research. 2015 01 Sep;12(8):736–44. PMID 2015398944. Ineligible study design26159192
Sakurai H, Hanyu H, Sato T, . Effects of cilostazol on cognition and regional cerebral blood flow in patients with Alzheimer’s disease and cerebrovascular disease: a pilot study. Geriatrics & gerontology international. 2013 Jan;13(1):90–7. PMID 22672107. Ineligible population22672107
Salloway S, Mintzer J, Cummings JL, . Subgroup analysis of US and non-US patients in a global study of high-dose donepezil (23 mg) in moderate and severe Alzheimer’s disease. American Journal of Alzheimer’s Disease & Other Dementias. 2012 Sep;27(6):421–32. PMID 22930699. Ineligible population22930699
Salloway S, Sperling R, Fox NC, . Two phase 3 trials of bapineuzumab in mild-to-moderate Alzheimer’s disease. New England Journal of Medicine. 2014 Jan 23;370(4):322–33. PMID 24450891. Ineligible population24450891
Salloway S, Sperling R, Gilman S, . A phase 2 multiple ascending dose trial of bapineuzumab in mild to moderate Alzheimer disease. Neurology. 2009 Dec 15;73(24):2061–70. PMID 19923550. Ineligible population19923550
Salloway S, Sperling R, Keren R, . A phase 2 randomized trial of ELND005, scyllo-inositol, in mild to moderate Alzheimer disease. Neurology. 2011 Sep 27;77(13):1253–62. PMID 21917766. Ineligible population21917766
Salvatore C, Cerasa A, Battista P, . Magnetic resonance imaging biomarkers for the early diagnosis of Alzheimer’s disease: A machine learning approach. Frontiers in Neuroscience. 2015;9 (SEP) (no pagination)(307)PMID 2015508042. Ineligible study design
Samieri C, Grodstein F, Rosner BA, . Mediterranean diet and cognitive function in older age. Epidemiology. 2013 Jul;24(4):490–9. PMID 23676264. Ineligible study design23676264
Sano M, Bell KL, Galasko D, . A randomized, double-blind, placebo-controlled trial of simvastatin to treat Alzheimer disease. Neurology. 2011 Aug 9;77(6):556–63. PMID 21795660. Ineligible population21795660
Sano M, Egelko S, Donohue M, . Developing dementia prevention trials: baseline report of the Home-Based Assessment study. Alzheimer Disease & Associated Disorders. 2013 Oct–Dec;27(4):356–62. PMID 23151596. Ineligible study design23151596
Sano M, Egelko S, Donohue MC, . Assessing clinical progression for dementia prevention trial: Results from the HBA trial [Journal: Conference Abstract]. 2014. http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/788/CN-01056788/frame.html10. Ineligible study design
Santoro A, Siviero P, Minicuci N, . Effects of donepezil, galantamine and rivastigmine in 938 Italian patients with Alzheimer’s disease: a prospective, observational study. CNS Drugs. 2010 Feb;24(2):163–76. PMID 20088621. Ineligible population20088621
Santos C, Costa J, Santos J, . Caffeine intake and dementia: systematic review and meta-analysis. Journal of Alzheimer’s Disease. 2010;20 Suppl 1:S187–204. PMID 20182026. Ineligible study design20182026
Santos-Galduroz RF, Galduroz JC, Facco RL, . Effects of isoflavone on the learning and memory of women in menopause: a double-blind placebo-controlled study. Brazilian Journal of Medical & Biological Research. 2010 Nov;43(11):1123–6. PMID 20945036. Inadequate follow up time20945036
Sato N, Saijo Y, Sasagawa Y, . Combination of antihypertensive therapy in the elderly, multicenter investigation (CAMUI) trial: results after 1 year. Journal of Hypertension. 2013 Jun;31(6):1245–55. PMID 23492647. No relevant outcomes reported23492647
Sato T, Hanyu H, Hirao K, . Efficacy of PPAR-gamma agonist pioglitazone in mild Alzheimer disease. Neurobiology of Aging. 2011 Sep;32(9):1626–33. PMID 19923038. Ineligible population19923038
Sattler C, Erickson KI, Toro P, . Physical fitness as a protective factor for cognitive impairment in a prospective population-based study in Germany. Journal of Alzheimer’s Disease. 2011;26(4):709–18. PMID 21694450. Cohort study with inadequate sample size21694450
Sattler C, Toro P, Schonknecht P, . Cognitive activity, education and socioeconomic status as preventive factors for mild cognitive impairment and Alzheimer’s disease. Psychiatry Research. 2012 Mar 30;196(1):90–5. PMID 22390831. Cohort study with inadequate sample size22390831
Saumier D, Duong A, Haine D, . Domain-specific cognitive effects of tramiprosate in patients with mild to moderate Alzheimer’s disease: ADAS-cog subscale results from the alphase study. Journal of Nutrition, Health and Aging. 2009;13(9):808–12. PMID 2009650262. Ineligible population
Scalf PE, Colcombe SJ, McCarley JS, . The neural correlates of an expanded functional field of view. Journals of Gerontology Series B-Psychological Sciences & Social Sciences. 2007 Jun;62 Spec No 1:32–44. PMID 17565163. Inadequate follow up time17565163
Scapagnini G, Sonya V, Nader AG, . Modulation of Nrf2/ARE pathway by food polyphenols: A nutritional neuroprotective strategy for cognitive and neurodegenerative disorders. Molecular Neurobiology. 2011 October;44(2):192–201. PMID 2011592755. Ineligible study design21499987
Scarmeas N, Luchsinger JA, Brickman AM, . Physical activity and Alzheimer disease course. American Journal of Geriatric Psychiatry. 2011 May;19(5):471–81. PMID 20808142. Ineligible study design20808142
Scarmeas N, Luchsinger JA, Schupf N, . Physical activity, diet, and risk of Alzheimer disease. JAMA. 2009 Aug 12;302(6):627–37. PMID 19671904. Cohort study with inadequate sample size19671904
Scarmeas N, Stern Y, Mayeux R, . Mediterranean diet and mild cognitive impairment. Archives of Neurology. 2009 Feb;66(2):216–25. PMID 19204158. Ineligible study design19204158
Scarpini E, Bruno G, Zappala G, . Cessation versus continuation of galantamine treatment after 12 months of therapy in patients with Alzheimer’s disease: a randomized, double blind, placebo controlled withdrawal trial. Journal of Alzheimer’s Disease. 2011;26(2):211–20. PMID 21606568. Ineligible population21606568
Schega L, Peter B, Torpel A, . Effects of intermittent hypoxia on cognitive performance and quality of life in elderly adults: a pilot study. Gerontology. 2013;59(4):316–23. PMID 23652274. Inadequate follow up time23652274
Scheltens P, Twisk JW, Blesa R, . Efficacy of Souvenaid in mild Alzheimer’s disease: results from a randomized, controlled trial. Journal of Alzheimer’s Disease. 2012;31(1):225–36. PMID 22766770. Ineligible population22766770
Schenck CH, Boeve BF, Mahowald MW. Delayed emergence of a parkinsonian disorder or dementia in 81% of older men initially diagnosed with idiopathic rapid eye movement sleep behavior disorder: a 16-year update on a previously reported series. Sleep Medicine. 2013 Aug;14(8):744–8. PMID 23347909. Ineligible study design23347909
Schiepers OJ, van Boxtel MP, de Groot RH, . Serum iron parameters, HFE C282Y genotype, and cognitive performance in older adults: results from the FACIT study. Journals of Gerontology Series A-Biological Sciences & Medical Sciences. 2010 Dec;65(12):1312–21. PMID 20813792. Ineligible study design20813792
Schiepers OJ, van Boxtel MP, de Groot RH, . DNA methylation and cognitive functioning in healthy older adults. British Journal of Nutrition. 2012 Mar;107(5):744–8. PMID 21791146. Cohort study with inadequate sample size21791146
Schifitto G, Yiannoutsos CT, Ernst T, . Selegiline and oxidative stress in HIV-associated cognitive impairment. Neurology. 2009 December;73(23):1975–81. PMID 2010015684. Ineligible population19890073
Schlesinger D, Grinberg LT, Alba JG, . African ancestry protects against Alzheimer’s disease-related neuropathology. Molecular Psychiatry. 2013 Jan;18(1):79–85. PMID 22064377. Ineligible study design22064377
Schmidt A, Hammann F, Wolnerhanssen B, . Green tea extract enhances parieto-frontal connectivity during working memory processing. Psychopharmacology. 2014 Oct;231(19):3879–88. PMID 24643507. Ineligible study design24643507
Schmitter-Edgecombe M, Dyck DG. Cognitive rehabilitation multi-family group intervention for individuals with mild cognitive impairment and their care-partners. Journal of the International Neuropsychological Society. 2014 Oct;20(9):897–908. PMID 25222630. Inadequate follow up time25222630
Schneider AL, Lutsey PL, Alonso A, . Vitamin D and cognitive function and dementia risk in a biracial cohort: the ARIC Brain MRI Study. European Journal of Neurology. 2014 Sep;21(9):1211–8, e69–70. PMID 24846449. Ineligible study design24846449
Schneider LS, Insel PS, Weiner MW, . Treatment with cholinesterase inhibitors and memantine of patients in the Alzheimer’s Disease Neuroimaging Initiative. Archives of Neurology. 2011 Jan;68(1):58–66. PMID 21220675. Inadequate follow up time21220675
Schneider P, Buerger K, Teipel S, . Antihypertensive therapy is associated with reduced rate of conversion to Alzheimer’s disease in midregional proatrial natriuretic peptide stratified subjects with mild cognitive impairment. Biological Psychiatry. 2011 Jul 15;70(2):145–51. PMID 21457948. Cohort study with inadequate sample size21457948
Schoene D, Valenzuela T, Toson B, . Interactive Cognitive-Motor Step Training Improves Cognitive Risk Factors of Falling in Older Adults - A Randomized Controlled Trial. PLoS ONE [Electronic Resource]. 2015;10(12):e0145161. PMID 26673919. Inadequate follow up time26673919
Scholey A, Ossoukhova A, Owen L, . Effects of American ginseng (Panax quinquefolius) on neurocognitive function: an acute, randomised, double-blind, placebo-controlled, crossover study. Psychopharmacology. 2010 Oct;212(3):345–56. PMID 20676609. Inadequate follow up time20676609
Schott JM, Reiniger L, Thom M, . Brain biopsy in dementia: clinical indications and diagnostic approach. Acta Neuropathologica. 2010 Sep;120(3):327–41. PMID 20640903. Cohort study with inadequate sample size20640903
Schrijvers EM, Witteman JC, Sijbrands EJ, . Insulin metabolism and the risk of Alzheimer disease: the Rotterdam Study. Neurology. 2010 Nov 30;75(22):1982–7. PMID 21115952. Ineligible population21115952
Schulz V. Ginkgo biloba extract for the prevention of dementia? Placebo-controlled 6-year prevention study without proof of efficacy. 2009. http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/812/CN-00756812/frame.html. Accessed on 1 30. Not available in English
Schwam E, Xu Y. Cognition and function in Alzheimer’s disease: identifying the transitions from moderate to severe disease. Dementia & Geriatric Cognitive Disorders. 2010;29(4):309–16. PMID 20395684. Ineligible study design20395684
Scogin F, Fairchild JK, Yon A, . Cognitive bibliotherapy and memory training for older adults with depressive symptoms. Aging & Mental Health. 2014 Jul;18(5):554–60. PMID 24073847. Inadequate follow up time24073847
Segal SK, Cotman CW, Cahill LF. Exercise-induced noradrenergic activation enhances memory consolidation in both normal aging and patients with amnestic mild cognitive impairment. Journal of Alzheimer’s Disease. 2012;32(4):1011–8. PMID 22914593. Inadequate follow up time22914593
Selnes OA, Grega MA, Bailey MM, . Do management strategies for coronary artery disease influence 6-year cognitive outcomes? Annals of Thoracic Surgery. 2009 Aug;88(2):445–54. PMID 19632391. Ineligible population19632391
Shah RC, Kamphuis PJ, Leurgans S, . The S-Connect study: Results from a randomized, controlled trial of Souvenaid in mild-to-moderate Alzheimer’s disease. Alzheimer’s Research and Therapy. 2013 26 Nov;5(6)PMID 2014019819. Ineligible population
Shao H, Breitner JC, Whitmer RA, . Hormone therapy and Alzheimer disease dementia: new findings from the Cache County Study. Neurology. 2012 Oct 30;79(18):1846–52. PMID 23100399. Ineligible study design23100399
Shatil E. Does combined cognitive training and physical activity training enhance cognitive abilities more than either alone? A four-condition randomized controlled trial among healthy older adults. Frontiers in Aging Neuroscience. 2013;5(MAR)PMID 2013561527. Inadequate follow up time
Shatil E, Mikulecka J, Bellotti F, . Novel television-based cognitive training improves working memory and executive function. PLoS ONE [Electronic Resource]. 2014;9(7):e101472. PMID 24992187. Inadequate follow up time24992187
Sherwin BB, Chertkow H, Schipper H, . A randomized controlled trial of estrogen treatment in men with mild cognitive impairment. Neurobiology of Aging. 2011 Oct;32(10):1808–17. PMID 20004499. Inadequate follow up time20004499
Sherwin BB, Grigorova M. Differential effects of estrogen and micronized progesterone or medroxyprogesterone acetate on cognition in postmenopausal women. Fertility & Sterility. 2011 Aug;96(2):399–403. PMID 21703613. Inadequate follow up time21703613
Shimizu S, Kanetaka H, Hirose D, . Differential effects of acetylcholinesterase inhibitors on clinical responses and cerebral blood flow changes in patients with Alzheimer’s disease: A 12-month, randomized, and open-label trial. Dementia and Geriatric Cognitive Disorders Extra. 2015;5(1):135–46. PMID 2015140257. Ineligible population25999980
Shin KY, Lee JY, Won BY, . BT-11 is effective for enhancing cognitive functions in the elderly humans. Neuroscience Letters. 2009 Nov 13;465(2):157–9. PMID 19699261. Inadequate follow up time19699261
Shinto L, Quinn J, Montine T, . A randomized placebo-controlled pilot trial of omega-3 fatty acids and alpha lipoic acid in Alzheimer’s disease. Journal of Alzheimer’s Disease. 2014;38(1):111–20. PMID 24077434. Ineligible population24077434
Silverman DH, Geist CL, Kenna HA, . Differences in regional brain metabolism associated with specific formulations of hormone therapy in postmenopausal women at risk for AD. Psychoneuroendocrinology. 2011 May;36(4):502–13. PMID 20810219. Inadequate follow up time20810219
Sittironnarit G, Ames D, Bush AI, . Effects of anticholinergic drugs on cognitive function in older Australians: results from the AIBL study. Dementia & Geriatric Cognitive Disorders. 2011;31(3):173–8. PMID 21389718. Ineligible population21389718
Siuda J, Gorzkowska A, Patalong-Ogiewa M, . From mild cognitive impairment to Alzheimer’s disease - influence of homocysteine, vitamin B12 and folate on cognition over time: results from one-year follow-up. Neurologia i Neurochirurgia Polska. 2009 Jul–Aug;43(4):321–9. PMID 19742390. Ineligible study design19742390
Small BJ, Dixon RA, McArdle JJ, . Do changes in lifestyle engagement moderate cognitive decline in normal aging? Evidence from the Victoria Longitudinal Study. Neuropsychology. 2012 Mar;26(2):144–55. PMID 22149165. Ineligible study design22149165
Smirni D, Turriziani P, Mangano GR, . Modulating memory performance in healthy subjects with transcranial direct current stimulation over the right dorsolateral prefrontal cortex. PLoS ONE. 2015 Dec;10(12)PMID 2016-00642-001. Inadequate follow up time
Smith GE, Housen P, Yaffe K, . A cognitive training program based on principles of brain plasticity: results from the Improvement in Memory with Plasticity-based Adaptive Cognitive Training (IMPACT) study. Journal of the American Geriatrics Society. 2009 Apr;57(4):594–603. PMID 19220558. Inadequate follow up time19220558
Smith PJ, Blumenthal JA, Babyak MA, . Effects of the dietary approaches to stop hypertension diet, exercise, and caloric restriction on neurocognition in overweight adults with high blood pressure. Hypertension. 2010 Jun;55(6):1331–8. PMID 20305128. Inadequate follow up time20305128
Smith PJ, Blumenthal JA, Hoffman BM, . Aerobic exercise and neurocognitive performance: a meta-analytic review of randomized controlled trials. Psychosomatic Medicine. 2010 Apr;72(3):239–52. PMID 20223924. Ineligible study design20223924
Smyth A, Dehghan M, O’Donnell M, . Healthy eating and reduced risk of cognitive decline: A cohort from 40 countries. Neurology. 2015 Jun 2;84(22):2258–65. PMID 25948720. Ineligible study design25948720
Sofi F, Abbate R, Gensini GF, . Accruing evidence on benefits of adherence to the Mediterranean diet on health: an updated systematic review and meta-analysis. American Journal of Clinical Nutrition. 2010 Nov;92(5):1189–96. PMID 20810976. Ineligible study design20810976
Solfrizzi V, Scafato E, Frisardi V, . Angiotensin-converting enzyme inhibitors and incidence of mild cognitive impairment. The Italian Longitudinal Study on Aging. Age. 2013 Apr;35(2):441–53. PMID 22203459. Ineligible study design22203459
Solomon A, Kareholt I, Ngandu T, . Serum total cholesterol, statins and cognition in non-demented elderly. Neurobiology of Aging. 2009 Jun;30(6):1006–9. PMID 18022292. Ineligible study design18022292
Solomon A, Kivipelto M, Wolozin B, . Midlife serum cholesterol and increased risk of Alzheimer’s and vascular dementia three decades later. Dementia & Geriatric Cognitive Disorders. 2009;28(1):75–80. PMID 19648749. Ineligible study design19648749
Solomon A, Sippola R, Soininen H, . Lipid-lowering treatment is related to decreased risk of dementia: a population-based study (FINRISK). Neurodegenerative Diseases. 2010;7(1–3):180–2. PMID 20224281. Ineligible study design20224281
Song Y, Nie H, Xu Y, . Association of statin use with risk of dementia: a meta-analysis of prospective cohort studies. Geriatrics & gerontology international. 2013 Oct;13(4):817–24. PMID 23461525. Ineligible study design23461525
Sonnen JA, Larson EB, Walker RL, . Nonsteroidal anti-inflammatory drugs are associated with increased neuritic plaques. Neurology. 2010 Sep 28;75(13):1203–10. PMID 20811000. Ineligible population20811000
Sorman DE, Sundstrom A, Ronnlund M, . Leisure activity in old age and risk of dementia: a 15-year prospective study. Journals of Gerontology Series B-Psychological Sciences & Social Sciences. 2014 Jul;69(4):493–501. PMID 23766435. Ineligible study design23766435
Soto ME, Secher M, Gillette-Guyonnet S, . Weight loss and rapid cognitive decline in community-dwelling patients with Alzheimer’s disease. Journal of Alzheimer’s Disease. 2012;28(3):647–54. PMID 22045479. Ineligible study design22045479
Soto ME, van Kan GA, Nourhashemi F, . Angiotensin-converting enzyme inhibitors and Alzheimer’s disease progression in older adults: results from the Reseau sur la Maladie d’Alzheimer Francais cohort. Journal of the American Geriatrics Society. 2013 Sep;61(9):1482–8. PMID 24000874. Ineligible population24000874
Spalletta G, Caltagirone C, Girardi P, . The role of persistent and incident major depression on rate of cognitive deterioration in newly diagnosed Alzheimer’s disease patients. Psychiatry Research. 2012 30 Jul;198(2):263–8. PMID 2012633360. Ineligible study design22406390
Spalletta G, Caltagirone C, Padovani A, . Cognitive and affective changes in mild to moderate Alzheimer’s disease patients undergoing switch of cholinesterase inhibitors: a 6-month observational study. PLoS ONE [Electronic Resource]. 2014;9(2):e89216. PMID 24586603. Cohort study with inadequate sample size24586603
Sparks DL, Kryscio RJ, Connor DJ, . Cholesterol and cognitive performance in normal controls and the influence of elective statin use after conversion to mild cognitive impairment: results in a clinical trial cohort. Neurodegenerative Diseases. 2010;7(1–3):183–6. PMID 20224282. Ineligible study design20224282
Sperling R, Johnson K. To sleep, perchance to delay dementia. Archives of Neurology. 2012 Jan;69(1):118–20. PMID 22232352. Ineligible study design22232352
Sperling RA, Rentz DM, Johnson KA, . The A4 study: Stopping AD before symptoms begin? Science Translational Medicine. 2014 19 Mar;6(228)PMID 2014282892. Ineligible study design
St John JA, Henderson VW, Hodis HN, . Associations between urine excretion of isoflavonoids and cognition in postmenopausal women in the Women’s Isoflavone Soy Health clinical trial. Journal of the American Geriatrics Society. 2014 Apr;62(4):629–35. PMID 24617349. Ineligible study design24617349
Steenland K, Zhao L, Goldstein FC, . Statins and cognitive decline in older adults with normal cognition or mild cognitive impairment. Journal of the American Geriatrics Society. 2013 September;61(9):1449–55. PMID 2013584156. Ineligible study design24000778
Stein EM, Loos S, Schneider A, . The effectiveness of regular physical activity and exercise in the prevention and treatment of cognitive impairment and early Alzheimer’s disease. [German] Regelmasige korperliche aktivitat als nichtpharmakologischer praventionsund behandlungsansatz im fruhstadium der Alzheimer-demenz. Neurologie und Rehabilitation. 2010;16(5):247–50. PMID 2011007309. Ineligible study design
Stein MS, Scherer SC, Ladd KS, . A randomized controlled trial of high-dose vitamin D2 followed by intranasal insulin in Alzheimer’s disease. Journal of Alzheimer’s Disease. 2011;26(3):477–84. PMID 21694461. Ineligible population21694461
Stephan BCM, Tzourio C, Auriacombe S, . Usefulness of data from magnetic resonance imaging to improve prediction of dementia: Population based cohort study. BMJ (Online). 2015 22 Jun;350 (no pagination)(h2863)PMID 2015303074. Ineligible study design
Stewart R, Xue QL, Masaki K, . Change in blood pressure and incident dementia: a 32-year prospective study. Hypertension. 2009 Aug;54(2):233–40. PMID 19564551. Ineligible study design19564551
Stough C, Downey L, Silber B, . The effects of 90-day supplementation with the omega-3 essential fatty acid docosahexaenoic acid (DHA) on cognitive function and visual acuity in a healthy aging population. Neurobiology of Aging. 2012 Apr;33(4):824.e1–3. PMID 21531481. Inadequate follow up time21531481
Strand BH, Langballe EM, Hjellvik V, . Midlife vascular risk factors and their association with dementia deaths: results from a Norwegian prospective study followed up for 35 years. Journal of the Neurological Sciences. 2013 Jan 15;324(1–2):124–30. PMID 23146611. Cohort study with inadequate sample size23146611
Strassnig MT, Signorile JF, Potiaumpai M, . High velocity circuit resistance training improves cognition, psychiatric symptoms and neuromuscular performance in overweight outpatients with severe mental illness. Psychiatry Research. 2015 Sep;229(1–2):295–301. PMID 2015-32473-001. Ineligible population26187340
Strobel G. Alzheimer’s prevention initiative. Journal of Alzheimer’s Disease. 2010;21(3):1025–35. PMID 20844340. Ineligible study design20844340
Stuart K, Summers MJ, Valenzuela MJ, . BDNF and COMT polymorphisms have a limited association with episodic memory performance or engagement in complex cognitive activity in healthy older adults. Neurobiology of learning and memory. 2014 01 Apr;110:1–7. PMID 24468545. Ineligible study design24468545
Styliadis C, Kartsidis P, Paraskevopoulos E, . Neuroplastic effects of combined computerized physical and cognitive training in elderly individuals at risk for dementia: an eLORETA controlled study on resting states. Neural Plasticity. 2015;2015:172192. PMID 25945260. Inadequate follow up time25945260
Sun L, Zhang XQ, Tang Z, . Cognitive function changes in patients with vascular dementia before and after symptom onset and analysis of its cognitive predictor. [Chinese]. Chinese Journal of Cerebrovascular Diseases. 2012 March;9(3):132–5. PMID 2012220434. Ineligible study design
Sun LM, Chen HJ, Liang JA, . Long-term use of tamoxifen reduces the risk of dementia: A nationwide population-based cohort study. Qjm. 2016 01 Feb;109(2):103–9. PMID 608857112. Ineligible population25852154
Sundelof J, Kilander L, Helmersson J, . Systemic tocopherols and F2-isoprostanes and the risk of Alzheimer’s disease and dementia: a prospective population-based study. Journal of Alzheimer’s Disease. 2009;18(1):71–8. PMID 19542632. Ineligible study design19542632
Suzuki H, Kuraoka M, Yasunaga M, . Cognitive intervention through a training program for picture book reading in community-dwelling older adults: a randomized controlled trial. BMC Geriatrics. 2014;14:122. PMID 25416537. Inadequate follow up time25416537
Sweetlove M. Phase III CONCERT trial of latrepirdine: Negative results. Pharmaceutical Medicine. 2012;26(2):113–5. PMID 2012165417. Ineligible population
Tadini L, El-Nazer R, Brunoni AR, . Cognitive, mood, and electroencephalographic effects of noninvasive cortical stimulation with weak electrical currents. Journal of ECT. 2011 Jun;27(2):134–40. PMID 20938352. Inadequate follow up time20938352
Tam CW, Lam LC. Clinical remission of late-onset depression in elderly Chinese: a short-term outcome study. East Asian Archives of Psychiatry. 2013 Sep;23(3):126–32. PMID 24088406. Ineligible study design24088406
Tanasugarn L, Natearpha P, Kongsakon R, . Physical effects and cognitive function after exercising “Rue-si-dad-ton” (exercise using the posture of the hermit doing body contortion): a randomized controlled pilot trial. Journal of the Medical Association of Thailand. 2015 Mar;98(3):306–13. PMID 25920302. Inadequate follow up time25920302
Tangwongchai S, Thavichachart N, Senanarong V, . Galantamine for the treatment of BPSD in Thai patients with possible Alzheimer’s disease with or without cerebrovascular disease. American Journal of Alzheimer’s Disease and other Dementias. 2009 December–January;23(6):593–601. PMID 2009009394. Ineligible population
Tao J, Liu J, Egorova N, . Increased hippocampus-medial prefrontal cortex resting-state functional connectivity and memory function after Tai Chi Chuan practice in elder adults. Frontiers in Aging Neuroscience. 2016;8(FEB) (no pagination)(25)PMID 608884975. Inadequate follow up time
Tariot P, Salloway S, Yardley J, . Long-term safety and tolerability of donepezil 23 mg in patients with moderate to severe Alzheimer’s disease. BMC Research Notes. 2012;5:283. PMID 22681723. Ineligible population22681723
Tariot PN, Schneider LS, Cummings J, . Chronic divalproex sodium to attenuate agitation and clinical progression of Alzheimer disease. Archives of General Psychiatry. 2011 Aug;68(8):853–61. PMID 21810649. Ineligible population21810649
Tasci I, Naharci MI, Bozoglu E, . Cognitive and functional influences of vildagliptin, a DPP-4 inhibitor, added to ongoing metformin therapy in elderly with type 2 diabetes. Endocrine, Metabolic & Immune Disorders Drug Targets. 2013 Sep;13(3):256–63. PMID 23848558. Ineligible study design23848558
Teixeira CV, Gobbi LT, Corazza DI, . Non-pharmacological interventions on cognitive functions in older people with mild cognitive impairment (MCI). Archives of Gerontology & Geriatrics. 2012 Jan–Feb;54(1):175–80. PMID 21397960. Ineligible study design21397960
Thiel C, Vogt L, Tesky VA, . Cognitive intervention response is related to habitual physical activity in older adults. Aging-Clinical & Experimental Research. 2012 Feb;24(1):47–55. PMID 21406956. Inadequate follow up time21406956
Thivierge S, Jean L, Simard M. A randomized cross-over controlled study on cognitive rehabilitation of instrumental activities of daily living in Alzheimer disease. American Journal of Geriatric Psychiatry. 2014 Nov;22(11):1188–99. PMID 23871120. Ineligible population23871120
Tierney MC, Ryan J, Ancelin ML, . Lifelong estrogen exposure and memory in older postmenopausal women. Journal of Alzheimer’s Disease. 2013;34(3):601–8. PMID 23246919. Ineligible study design23246919
Tolppanen AM, Solomon A, Kulmala J, . Leisure-time physical activity from mid- to late life, body mass index, and risk of dementia. Alzheimer’s & Dementia. 2015 Apr;11(4):434–43.e6. PMID 24721528. Ineligible study design24721528
Tranah GJ, Blackwell T, Stone KL, . Circadian activity rhythms and risk of incident dementia and mild cognitive impairment in older women. Annals of Neurology. 2011 Nov;70(5):722–32. PMID 22162057. Ineligible study design22162057
Tsai PF, Chang JY, Beck C, . A pilot cluster-randomized trial of a 20-week tai chi program in elders with cognitive impairment and osteoarthritic knee: Effects on pain and other health outcomes. Journal of Pain and Symptom Management. 2013 April;45(4):660–9. PMID 2013213752. Inadequate follow up time23017610
Tsantali E, Economidis D. Implications of a longitudinal cognitive intervention program in mild Alzheimer’s disease. Archives of Psychiatric Nursing. 2014 Apr;28(2):128–34. PMID 24673788. Ineligible population24673788
Tseng CH, Huang WS, Muo CH, . Increased risk of dementia among chronic osteomyelitis patients. European Journal of Clinical Microbiology & Infectious Diseases. 2015 Jan;34(1):153–9. PMID 25098680. Not cognitive decline prevention intervention25098680
Tsivgoulis G, Judd S, Letter AJ, . Adherence to a Mediterranean diet and risk of incident cognitive impairment. Neurology. 2013 Apr 30;80(18):1684–92. PMID 23628929. Not cognitive decline prevention intervention23628929
Tzimopoulou S, Cunningham VJ, Nichols TE, . A multi-center randomized proof-of-concept clinical trial applying [ 18F]FDG-PET for evaluation of metabolic therapy with rosiglitazone XR in mild to moderate Alzheimer’s disease. Journal of Alzheimer’s Disease. 2010;22(4):1241–56. PMID 2011081259. Ineligible study design
Tzourio C, Anderson C, Chapman N, . Effects of blood pressure lowering with perindopril and indapamide therapy on dementia and cognitive decline in patients with cerebrovascular disease. Archives of Internal Medicine. 2003 May 12;163(9):1069–75. PMID 12742805. Ineligible population12742805
Ukawa S, Yuasa M, Ikeno T, . Randomised controlled pilot study in Japan comparing a home visit program using a Functioning Improvement Tool with a home visit with conversation alone. Australasian Journal on Ageing. 2012 September;31(3):187–9. PMID 22950591. Inadequate follow up time22950591
Vaillant GE, Okereke OI, Mukamal K, . Antecedents of intact cognition and dementia at age 90 years: a prospective study. International Journal of Geriatric Psychiatry. 2014 Dec;29(12):1278–85. PMID 24733646. Cohort study with inadequate sample size24733646
Valen-Sendstad A, Engedal K, Stray-Pedersen B, . Effects of hormone therapy on depressive symptoms and cognitive functions in women with Alzheimer disease: a 12 month randomized, double-blind, placebo-controlled study of low-dose estradiol and norethisterone. American Journal of Geriatric Psychiatry. 2010 Jan;18(1):11–20. PMID 20094015. Ineligible population20094015
van de Rest O, Berendsen AA, Haveman-Nies A, . Dietary patterns, cognitive decline, and dementia: a systematic review. Advances in Nutrition. 2015 Mar;6(2):154–68. PMID 25770254. Ineligible study design25770254
van de Rest O, van der Zwaluw NL, de Groot LC. Literature review on the role of dietary protein and amino acids in cognitive functioning and cognitive decline. Amino Acids. 2013 Nov;45(5):1035–45. PMID 23990160. Ineligible study design23990160
van der Schaft J, Koek HL, Dijkstra E, . The association between vitamin D and cognition: a systematic review. Ageing Research Reviews. 2013 Sep;12(4):1013–23. PMID 23727408. Ineligible study design23727408
van Himbergen TM, Beiser AS, Ai M, . Biomarkers for insulin resistance and inflammation and the risk for all-cause dementia and alzheimer disease: results from the Framingham Heart Study. Archives of Neurology. 2012 May;69(5):594–600. PMID 22213409. No relevant outcomes reported22213409
van Paasschen J, Clare L, Yuen KS, . Cognitive rehabilitation changes memory-related brain activity in people with Alzheimer disease. Neurorehabilitation & Neural Repair. 2013 Jun;27(5):448–59. PMID 23369983. Ineligible population23369983
van Uffelen JG, Chinapaw MJ, Hopman-Rock M, . Feasibility and effectiveness of a walking program for community-dwelling older adults with mild cognitive impairment. Journal of Aging & Physical Activity. 2009 Oct;17(4):398–415. PMID 19940321. Not cognitive decline prevention intervention19940321
Van Vleet TM, DeGutis JM, Merzenich MM, . Targeting Alertness to Improve Cognition in Older Adults: A Preliminary Report of Benefits in Executive Function and Skill Acquisition. Cortex. 2016. Ineligible study design
Vandewoude MFJ. Management of patients with mild cognitive impairment and mild to moderate dementia. Acta Clinica Belgica. 2009 March/April;64(2):92–9. PMID 2009191218. Ineligible population19432021
Vaughan C, Goldstein FC, Tenover JL. Exogenous testosterone alone or with finasteride does not improve measurements of cognition in healthy older men with low serum testosterone. Journal of Andrology. 2007 Nov–Dec;28(6):875–82. PMID 17609296. Not cognitive decline prevention intervention17609296
Vaughan L, Espeland MA, Snively B, . The rationale, design, and baseline characteristics of the Women’s Health Initiative Memory Study of Younger Women (WHIMS-Y). Brain Research. 2013 Jun 13;1514:3–11. PMID 23578696. Ineligible study design23578696
Vedin I, Cederholm T, Freund-Levi Y, . Effects of DHA-rich n-3 fatty acid supplementation on gene expression in blood mononuclear leukocytes: the OmegAD study. PLoS ONE [Electronic Resource]. 2012;7(4):e35425. PMID 22545106. Ineligible population22545106
Vedin I, Cederholm T, Freund-Levi Y, . Reduced prostaglandin F2 alpha release from blood mononuclear leukocytes after oral supplementation of omega3 fatty acids: the OmegAD study. Journal of Lipid Research. 2010 May;51(5):1179–85. PMID 19965584. Ineligible population19965584
Vellas B, Black R, Thal LJ, . Long-term follow-up of patients immunized with AN1792: Reduced functional decline in antibody responders. Current Alzheimer Research. 2009 April;6(2):144–51. PMID 2009182642. Ineligible population19355849
Vellas B, Carrie I, Gillette-Guyonnet S, . MAPT study: a multidomain approach for preventing Alzheimer’s disease: design and baseline data. The journal of prevention of Alzheimer’s disease. 2014;1(1):13. Ineligible study design
Venturelli M, Scarsini R, Schena F. Six-month walking program changes cognitive and ADL performance in patients with Alzheimer. American Journal of Alzheimer’s Disease & Other Dementias. 2011 Aug;26(5):381–8. PMID 21852281. Ineligible population21852281
Vercambre MN, Berr C, Ritchie K, . Caffeine and cognitive decline in elderly women at high vascular risk. Journal of Alzheimer’s Disease. 2013;35(2):413–21. PMID 23422357. Not cognitive decline prevention intervention23422357
Vercambre MN, Grodstein F, Kang JH. Dietary fat intake in relation to cognitive change in high-risk women with cardiovascular disease or vascular factors. European Journal of Clinical Nutrition. 2010 Oct;64(10):1134–40. PMID 20648044. Not cognitive decline prevention intervention20648044
Verdelho A, Madureira S, Ferro JM, . Physical activity prevents progression for cognitive impairment and vascular dementia: results from the LADIS (Leukoaraiosis and Disability) study. Stroke. 2012 Dec;43(12):3331–5. PMID 23117721. Not cognitive decline prevention intervention23117721
Vigen CL, Mack WJ, Keefe RS, . Cognitive effects of atypical antipsychotic medications in patients with Alzheimer’s disease: outcomes from CATIE-AD. American Journal of Psychiatry. 2011 Aug;168(8):831–9. PMID 21572163. Ineligible population21572163
Viola S, Viola P, Buongarzone MP, . New brain reperfusion rehabilitation therapy improves cognitive impairment in mild alzheimer’s disease: A prospective, controlled, open-label 12-month study with nirs correlates. Aging Clinical and Experimental Research. 2014;26(4):417–25. PMID 2015687983. Ineligible population24338518
Virta JJ, Heikkila K, Perola M, . Midlife cardiovascular risk factors and late cognitive impairment. European Journal of Epidemiology. 2013 May;28(5):405–16. PMID 23532744. No relevant outcomes reported23532744
Viswanathan A. High-dose B vitamin supplementation as a disease-modifying therapy in alzheimer disease. Archives of Neurology. 2009 April;66(4):520–2. PMID 2009196917. Ineligible population19364938
Viswanathan A, Raj S, Greenberg SM, . Plasma Abeta, homocysteine, and cognition: the Vitamin Intervention for Stroke Prevention (VISP) trial. Neurology. 2009 Jan 20;72(3):268–72. PMID 19153374. Ineligible population19153374
Voigt-Radloff S, Hull M. [Daily functioning in dementia: pharmacological and non-pharmacological interventions demonstrate small effects on heterogeneous scales]. Psychiatrische Praxis. 2011 Jul;38(5):221–31. PMID 21425035. Ineligible population21425035
Voss MW, Erickson KI, Prakash RS, . Neurobiological markers of exercise-related brain plasticity in older adults. Brain, Behavior, & Immunity. 2013 Feb;28:90–9. PMID 23123199. No relevant outcomes reported23123199
Vranic A, Spanic AM, Carretti B, . The efficacy of a multifactorial memory training in older adults living in residential care settings. International Psychogeriatrics. 2013 Nov;25(11):1885–97. PMID 23899952. Ineligible population23899952
Wade AG, Farmer M, Harari G, . Add-on prolonged-release melatonin for cognitive function and sleep in mild to moderate Alzheimer’s disease: a 6-month, randomized, placebo-controlled, multicenter trial. Clinical Interventions In Aging. 2014;9:947–61. PMID 24971004. Ineligible population24971004
Wagner G, Icks A, Abholz HH, . Antihypertensive treatment and risk of dementia: a retrospective database study.[Erratum appears in Int J Clin Pharmacol Ther. 2012 Nov;50(11):850]. International Journal of Clinical Pharmacology & Therapeutics. 2012 Mar;50(3):195–201. PMID 22373832. Ineligible study design22373832
Wagner S, Paulsen S, Bleichner F, . Cognitive training in rehabilitation: a program to treat mild cognitive impairment. [German] Gedachtnismanagementtraining in der Rehabilitation (KTR): Programm zur Behandlung leichter kognitiver Beeintrachtigungen. Zeitschrift fur Gerontologie und Geriatrie : Organ der Deutschen Gesellschaft fur Gerontologie und Geriatrie. 2009 Dec;42(6):479–87. PMID 19543680. Not available in English19543680
Wagner S, Paulsen S, Bleichner F, . [Cognitive training in rehabilitation: a program to treat mild cognitive impairment]. Zeitschrift fur Gerontologie und Geriatrie. 2009 Dec;42(6):479–87. PMID 19543680. Ineligible population19543680
Waldorff FB, Buss DV, Eckermann A, . Efficacy of psychosocial intervention in patients with mild Alzheimer’s disease: The multicentre, rater blinded, randomised Danish Alzheimer Intervention Study (DAISY). BMJ (Online). 2012 18 Aug;345(7870)PMID 2012491882. Ineligible population
Wallin AK, Wattmo C, Minthon L. Galantamine treatment in Alzheimer’s disease: Response and long-term outcome in a routine clinical setting. Neuropsychiatric Disease and Treatment. 2011;7(1):565–76. PMID 2011624724. Ineligible population22003296
Wallin K, Solomon A, Kareholt I, . Midlife rheumatoid arthritis increases the risk of cognitive impairment two decades later: a population-based study. Journal of Alzheimer’s Disease. 2012;31(3):669–76. PMID 22647255. Not cognitive decline prevention intervention22647255
Wang HK, Lin SH, Sung PS, . Population based study on patients with traumatic brain injury suggests increased risk of dementia. Journal of Neurology, Neurosurgery & Psychiatry. 2012 Nov;83(11):1080–5. PMID 22842203. Ineligible population22842203
Wang HX, Karp A, Herlitz A, . Personality and lifestyle in relation to dementia incidence. Neurology. 2009 Jan 20;72(3):253–9. PMID 19153372. No relevant outcomes reported19153372
Wang HX, Wahlberg M, Karp A, . Psychosocial stress at work is associated with increased dementia risk in late life. Alzheimer’s & Dementia. 2012;8(2):114–20. PMID 22404853. No relevant outcomes reported22404853
Wang JR, Hsieh S. Neurofeedback training improves attention and working memory performance. Clinical Neurophysiology. 2013 Dec;124(12):2406–20. PMID 23827814. Inadequate follow up time23827814
Wang LP, Zhang XY, Liu N, . Comparison of integrated traditional Chinese and western medicine therapy on vascular cognitive impairment with no dementia. Genetics and Molecular Research. 2015 11 May;14(2):4896–902. PMID 2015041645. Ineligible population25966264
Wang LQ, Chien WT. Randomised controlled trial of a family-led mutual support programme for people with dementia. Journal of Clinical Nursing. 2011 August;20(15–16):2362–6. PMID 21752121. Ineligible population21752121
Wang LY, Larson EB, Sonnen JA, . Blood pressure and brain injury in older adults: Findings from a community-based autopsy study. Journal of the American Geriatrics Society. 2009 November;57(11):1975–81. PMID 2009560327. Cohort study with inadequate sample size19793158
Wang S, Jacobs D, Andrews H, . Cardiovascular risk and memory in non-demented elderly women. Neurobiology of Aging. 2010 Jul;31(7):1250–3. PMID 18805604. Not cognitive decline prevention intervention18805604
Wang S, Luo X, Barnes D, . Physical activity and risk of cognitive impairment among oldest-old women. American Journal of Geriatric Psychiatry. 2014 Nov;22(11):1149–57. PMID 23831179. Not cognitive decline prevention intervention23831179
Wang T, Huang Q, Reiman EM, . Effects of memantine on clinical ratings, fluorodeoxyglucose positron emission tomography measurements, and cerebrospinal fluid assays in patients with moderate to severe Alzheimer dementia: a 24-week, randomized, clinical trial. Journal of Clinical Psychopharmacology. 2013 Oct;33(5):636–42. PMID 23948786. Ineligible population23948786
Wang X, Hjorth E, Vedin I, . Effects of n-3 FA supplementation on the release of proresolving lipid mediators by blood mononuclear cells: The omegAD study. Journal of Lipid Research. 2015 01 Mar;56(3):674–81. PMID 2015856468. Ineligible population25616438
Wardle J, Armitage J, Collins R, . Randomised placebo controlled trial of effect on mood of lowering cholesterol concentration. Oxford Cholesterol Study Group. BMJ. 1996 Jul 13;313(7049):75–8. PMID 8688757. No relevant outcomes reported8688757
Wardle J, Rogers P, Judd P, . Randomized trial of the effects of cholesterol-lowering dietary treatment on psychological function. American Journal of Medicine. 2000 May;108(7):547–53. PMID 10806283. Inadequate follow up time10806283
Watfa G, Rossignol P, Kearney-Schwartz A, . Use of calcium channel blockers is associated with better cognitive performance in older hypertensive patients with subjective memory complaints. Journal of Hypertension. 2010 December;28(12):2485–93. PMID 2012369475. Ineligible study design20739903
Watson GS, Baker LD, Cholerton BA, . Effects of insulin and octreotide on memory and growth hormone in Alzheimer’s disease. Journal of Alzheimer’s Disease. 2009;18(3):595–602. PMID 19625744. Ineligible population19625744
Wattmo C, Londos E, Minthon L. Solitary living in Alzheimer’s disease over 3 years: association between cognitive and functional impairment and community-based services. Clinical Interventions In Aging. 2014;9:1951–62. PMID 25484578. Ineligible population25484578
Wattmo C, Wallin AK, Londos E, . Long-term outcome and prediction models of activities of daily living in Alzheimer disease with cholinesterase inhibitor treatment. Alzheimer Disease & Associated Disorders. 2011 Jan–Mar;25(1):63–72. PMID 20847636. Ineligible population20847636
Wattmo C, Wallin AK, Minthon L. Functional response to cholinesterase inhibitor therapy in a naturalistic Alzheimer’s disease cohort. BMC Neurology. 2012;12:134. PMID 23126532. Ineligible population23126532
Wei XH, Ji LL. Effect of handball training on cognitive ability in elderly with mild cognitive impairment. Neuroscience Letters. 2014 Apr 30;566:98–101. PMID 24582900. Ineligible population24582900
Weiner MW, Sadowsky C, Saxton J, . Magnetic resonance imaging and neuropsychological results from a trial of memantine in Alzheimer’s disease. Alzheimer’s & Dementia. 2011 Jul;7(4):425–35. PMID 21646051. Ineligible population21646051
Weinstein G, Beiser AS, Choi SH, . Serum brain-derived neurotrophic factor and the risk for dementia: the Framingham Heart Study. JAMA Neurology. 2014 Jan;71(1):55–61. PMID 24276217. Not cognitive decline prevention intervention24276217
Weintraub D, Rosenberg PB, Drye LT, . Sertraline for the treatment of depression in Alzheimer disease: week-24 outcomes. American Journal of Geriatric Psychiatry. 2010 Apr;18(4):332–40. PMID 20220589. Ineligible population20220589
Weintraub D, Somogyi M, Meng X. Rivastigmine in alzheimer’s disease and Parkinson’s disease dementia: An ADAS-Cog factor analysis. American Journal of Alzheimer’s Disease and other Dementias. 2011 September;26(6):443–9. PMID 2012001003. Ineligible population
Welmer AK, Rizzuto D, Qiu C, . Walking speed, processing speed, and dementia: a population-based longitudinal study. Journals of Gerontology Series A-Biological Sciences & Medical Sciences. 2014 Dec;69(12):1503–10. PMID 24706441. Not cognitive decline prevention intervention24706441
Wenger NS, Roth CP, Shekelle PG, . A practice-based intervention to improve primary care for falls, urinary incontinence, and dementia. Journal of the American Geriatrics Society. 2009 Mar;57(3):547–55. PMID 19175441. No relevant outcomes reported19175441
Werner NS, Duschek S, Schandry R. D-camphor-crataegus berry extract combination increases blood pressure and cognitive functioning in the elderly - a randomized, placebo controlled double blind study. Phytomedicine. 2009 Dec;16(12):1077–82. PMID 19560327. Inadequate follow up time19560327
Westwoo W, Beiser A, DeCarli C, . Insulin-like growth factor-1 and risk of Alzheimer dementia and brain atrophy. Neurology. 2014 06 May;82(18):1613–9. PMID 2014392068. Not cognitive decline prevention intervention24706014
Weyerer S, Schaufele M, Wiese B, . Current alcohol consumption and its relationship to incident dementia: results from a 3-year follow-up study among primary care attenders aged 75 years and older. Age & Ageing. 2011 Jul;40(4):456–63. PMID 21367764. Not cognitive decline prevention intervention21367764
Whalley LJ, Duthie SJ, Collins AR, . Homocysteine, antioxidant micronutrients and late onset dementia. European Journal of Nutrition. 2014 Feb;53(1):277–85. PMID 23625136. Not cognitive decline prevention intervention23625136
Whalley LJ, Sharma S, Fox HC, . Anticholinergic drugs in late life: adverse effects on cognition but not on progress to dementia. Journal of Alzheimer’s Disease. 2012;30(2):253–61. PMID 22426015. Cohort study with inadequate sample size22426015
Wharton W, Baker LD, Gleason CE, . Short-term hormone therapy with transdermal estradiol improves cognition for postmenopausal women with Alzheimer’s disease: results of a randomized controlled trial. Journal of Alzheimer’s Disease. 2011;26(3):495–505. PMID 21694454. Ineligible population21694454
Wharton W, Gleason CE, Dowling NM, . The KEEPS-Cognitive and Affective Study: baseline associations between vascular risk factors and cognition. Journal of Alzheimer’s Disease. 2014;40(2):331–41. PMID 24430001. Not cognitive decline prevention intervention24430001
White RS, Lipton RB, Hall CB, . Nonmelanoma skin cancer is associated with reduced Alzheimer disease risk. Neurology. 2013 May 21;80(21):1966–72. PMID 23677746. Not cognitive decline prevention intervention23677746
White WB, Marfatia R, Schmidt J, . INtensive versus standard ambulatory blood pressure lowering to prevent functional DeclINe in the ElderlY (INFINITY). American Heart Journal. 2013 Mar;165(3):258–65.e1. PMID 23453090. Ineligible population23453090
Whitehair DC, Sherzai A, Emond J, . Influence of apolipoprotein E varepsilon4 on rates of cognitive and functional decline in mild cognitive impairment. Alzheimer’s & Dementia. 2010 Sep;6(5):412–9. PMID 20813342. Ineligible study design20813342
Whitlock JA, Jr.. Brain injury, cognitive impairment, and donepezil. Journal of Head Trauma Rehabilitation. 1999 Aug;14(4):424–7. PMID 10407214. Ineligible study design10407214
Whitmer RA, Quesenberry CP, Zhou J, . Timing of hormone therapy and dementia: the critical window theory revisited. Annals of Neurology. 2011 Jan;69(1):163–9. PMID 21280086. No relevant outcomes reported21280086
Wightman EL, Reay JL, Haskell CF, . Effects of resveratrol alone or in combination with piperine on cerebral blood flow parameters and cognitive performance in human subjects: a randomised, double-blind, placebo-controlled, cross-over investigation. British Journal of Nutrition. 2014 Jul;112(2):203–13. PMID 24804871. Inadequate follow up time24804871
Wilkinson D, Fox NC, Barkhof F, . Memantine and brain atrophy in Alzheimer’s disease: a 1-year randomized controlled trial. Journal of Alzheimer’s Disease. 2012;29(2):459–69. PMID 22269160. Ineligible population22269160
Wilkinson D, Roman G, Salloway S, . The long-term efficacy and tolerability of donepezil in patients with vascular dementia. International Journal of Geriatric Psychiatry. 2010 Mar;25(3):305–13. PMID 19623601. Ineligible population19623601
Wilkinson D, Schindler R, Schwam E, . Effectiveness of donepezil in reducing clinical worsening in patients with mild-to-moderate alzheimer’s disease. Dementia & Geriatric Cognitive Disorders. 2009;28(3):244–51. PMID 19786776. Ineligible population19786776
Wilkinson D, Windfeld K, Colding-Jorgensen E. Safety and efficacy of idalopirdine, a 5-HT6 receptor antagonist, in patients with moderate Alzheimer’s disease (LADDER): a randomised, double-blind, placebo-controlled phase 2 trial. Lancet Neurology. 2014 Nov;13(11):1092–9. PMID 25297016. Ineligible population25297016
Williams PT. Lower risk of Alzheimer’s disease mortality with exercise, statin, and fruit intake. Journal of Alzheimer’s Disease. 2015;44(4):1121–9. PMID 25408208. Ineligible population25408208
Wilson RS, Barnes LL, Aggarwal NT, . Cognitive activity and the cognitive morbidity of Alzheimer disease. Neurology. 2010 Sep 14;75(11):990–6. PMID 20811001. Ineligible population20811001
Winblad B, Black SE, Homma A, . Donepezil treatment in severe Alzheimer’s disease: a pooled analysis of three clinical trials. Current Medical Research & Opinion. 2009 Nov;25(11):2577–87. PMID 19735164. Ineligible population19735164
Winblad B, Gauthier S, Astrom D, . Memantine benefits functional abilities in moderate to severe Alzheimer’s disease. Journal of Nutrition, Health & Aging. 2010 Nov;14(9):770–4. PMID 21085908. Ineligible population21085908
Winblad B, Giacobini E, Frolich L, . Phenserine efficacy in Alzheimer’s disease. Journal of Alzheimer’s Disease. 2010;22(4):1201–8. PMID 20930279. Ineligible population20930279
Winchester J, Dick MB, Gillen D, . Walking stabilizes cognitive functioning in Alzheimer’s disease (AD) across one year. Archives of Gerontology & Geriatrics. 2013 Jan–Feb;56(1):96–103. PMID 22959822. Ineligible population22959822
Wingenfeld K, Kuffel A, Uhlmann C, . Effects of noradrenergic stimulation on memory in patients with major depressive disorder. Stress. 2013 Mar;16(2):191–201. PMID 22746337. Inadequate follow up time22746337
Winslow BT, Onysko MK, Stob CM, . Treatment of Alzheimer disease. American Family Physician. 2011 June;83(12):1403–12. PMID 2011343700. Ineligible population21671540
Wolkenstein L, Plewnia C. Amelioration of cognitive control in depression by transcranial direct current stimulation. Biological Psychiatry. 2013 Apr 1;73(7):646–51. PMID 23219367. No relevant outcomes reported23219367
Wolozin B, Wang SW, Li NC, . Simvastatin is associated with a reduced incidence of dementia and Parkinson’s disease. BMC Medicine. 2007;5:20. PMID 17640385. Ineligible study design17640385
Wong RH, Howe PR, Bryan J, . Chronic effects of a wild green oat extract supplementation on cognitive performance in older adults: a randomised, double-blind, placebo-controlled, crossover trial. Nutrients. 2012 May;4(5):331–42. PMID 22690320. Inadequate follow up time22690320
Wright RM, Roumani YF, Boudreau R, . Effect of central nervous system medication use on decline in cognition in community-dwelling older adults: findings from the Health, Aging And Body Composition Study. Journal of the American Geriatrics Society. 2009 Feb;57(2):243–50. PMID 19207141. Ineligible study design19207141
Wroolie TE, Kenna HA, Williams KE, . Differences in verbal memory performance in postmenopausal women receiving hormone therapy: 17beta-estradiol versus conjugated equine estrogens. American Journal of Geriatric Psychiatry. 2011 Sep;19(9):792–802. PMID 21873835. Ineligible study design21873835
Wroolie TE, Kenna HA, Williams KE, . Cognitive effects of memantine in postmenopausal women at risk of dementia: a pilot study. Acta Neurologica Scandinavica. 2009 Mar;119(3):172–9. PMID 18705678. Ineligible study design18705678
Wu MS, Lan TH, Chen CM, . Socio-demographic and health-related factors associated with cognitive impairment in the elderly in Taiwan. BMC Public Health. 2011;11:22. PMID 21223555. Ineligible study design21223555
Wucherer D, Eichler T, Kilimann I, . Antidementia drug treatment in people screened positive for dementia in primary care. Journal of Alzheimer’s Disease. 2015;44(3):1015–21. PMID 25391382. Ineligible population25391382
Xiu LL, Wahlqvist ML, Lee MS, . Cognitive impairment and limited dietary diversity or physical inactivity are conjoint precursors of incident diabetes more so in elderly women than men. Asia Pacific Journal of Clinical Nutrition. 2013;22(4):635–45. PMID 24231025. Ineligible study design24231025
Xu WL, von Strauss E, Qiu CX, . Uncontrolled diabetes increases the risk of Alzheimer’s disease: a population-based cohort study. Diabetologia. 2009 Jun;52(6):1031–9. PMID 19280172. Ineligible study design19280172
Xu ZQ, Liang XM, Juan W, . Treatment with Huperzine A improves cognition in vascular dementia patients. Cell Biochemistry & Biophysics. 2012 Jan;62(1):55–8. PMID 21833673. Ineligible population21833673
Yaffe K, Falvey CM, Hamilton N, . Association between hypoglycemia and dementia in a biracial cohort of older adults with diabetes mellitus. JAMA Internal Medicine. 2013 22 Jul;173(14):1300–6. PMID 2013468296. Ineligible study design23753199
Yakoot M, Salem A, Helmy S. Effect of Memo, a natural formula combination, on Mini-Mental State Examination scores in patients with mild cognitive impairment. Clinical Interventions In Aging. 2013;8:975–81. PMID 23950642. Inadequate follow up time23950642
Yamada S, Akishita M, Fukai S, . Effects of dehydroepiandrosterone supplementation on cognitive function and activities of daily living in older women with mild to moderate cognitive impairment. Geriatrics & gerontology international. 2010 Oct;10(4):280–7. PMID 20497239. Ineligible population20497239
Yamamoto T, Kondo K, Hirai H, . Association between self-reported dental health status and onset of dementia: A 4-year prospective cohort study of older Japanese adults from the Aichi Gerontological Evaluation Study (AGES) Project. Psychosomatic Medicine. 2012 April;74(3):241–8. PMID 2012211620. Ineligible study design22408130
Yamashita T, Ogasawara K, Kuroda H, . Combination of preoperative cerebral blood flow and 123I-iomazenil SPECT imaging predicts postoperative cognitive improvement in patients undergoing uncomplicated endarterectomy for unilateral carotid stenosis. Clinical Nuclear Medicine. 2012 Feb;37(2):128–33. PMID 22228333. Ineligible population22228333
Yancheva S, Ihl R, Nikolova G, . Ginkgo biloba extract EGb 761, donepezil or both combined in the treatment of Alzheimer’s disease with neuropsychiatric features: A randomised, double-blind, exploratory trial. Aging and Mental Health. 2009 March;13(2):183–90. PMID 2009516891. Ineligible population19347685
Yancheva S, Ihl R, Nikolova G, . Ginkgo biloba extract EGb 761(R), donepezil or both combined in the treatment of Alzheimer’s disease with neuropsychiatric features: a randomised, double-blind, exploratory trial. Aging & Mental Health. 2009 Mar;13(2):183–90. PMID 19347685. Ineligible population19347685
Yang BF, Zeng XH, Liu Y, . Effect of acupuncture treatment on vascular cognitive impairment without dementia: study protocol for a randomized controlled trial. Trials [Electronic Resource]. 2014;15:442. PMID 25391431. Ineligible study design25391431
Yang CM, Shen YC, Weng SF, . Increased Risk of Dementia in Patients With Erectile Dysfunction: A Population-Based, Propensity Score-Matched, Longitudinal Follow-Up Study. Medicine. 2015 Jun;94(24):e990. PMID 26091478. Ineligible study design26091478
Yang YH, Chen CH, Chou MC, . Concentration of donepezil to the cognitive response in Alzheimer disease. Journal of Clinical Psychopharmacology. 2013 Jun;33(3):351–5. PMID 23609381. Ineligible population23609381
Yang YH, Teng HW, Lai YT, . Statins reduces the risk of dementia in patients with late-onset depression: A retrospective cohort study. PLoS ONE. 2015 18 Sep;10(9) (no pagination)(e0137914)PMID 2015503958. Ineligible study design
Yang Z, Zhou X, Zhang Q. Effectiveness and safety of memantine treatment for Alzheimer’s disease. Journal of Alzheimer’s Disease. 2013;36(3):445–58. PMID 2013505142. Ineligible population
Yannakoulia M, Kontogianni M, Scarmeas N. Cognitive health and Mediterranean diet: just diet or lifestyle pattern? Ageing Research Reviews. 2015 Mar;20:74–8. PMID 25461244. Ineligible study design25461244
Yasar S, Lin FM, Fried LP, . Diuretic use is associated with better learning and memory in older adults in the Ginkgo Evaluation of Memory Study. Alzheimer’s & Dementia. 2012 May;8(3):188–95. PMID 22465175. Not cognitive decline prevention intervention22465175
Yasar S, Xia J, Yao W, . Antihypertensive drugs decrease risk of Alzheimer disease: Ginkgo Evaluation of Memory Study. Neurology. 2013 Sep 3;81(10):896–903. PMID 23911756. Not cognitive decline prevention intervention23911756
Ye R, Hu Y, Yao A, . Impact of renin - angiotensin system-targeting antihypertensive drugs on treatment of Alzheimer’s disease: A meta-analysis. International Journal of Clinical Practice. 2015 01 Jun;69(6):674–81. PMID 2015077237. Ineligible study design25721930
Yeh YC, Liu CL, Peng LN, . Potential benefits of reducing medication-related anticholinergic burden for demented older adults: a prospective cohort study. Geriatrics & gerontology international. 2013 Jul;13(3):694–700. PMID 23216534. Ineligible population23216534
Yesavage JA, Mumenthaler MS, Taylor JL, . Donepezil and flight simulator performance: effects on retention of complex skills. Neurology. 2002 Jul 9;59(1):123–5. PMID 12105320. Inadequate follow up time12105320
Yeung CM, St John PD, Menec V, . Is bilingualism associated with a lower risk of dementia in community-living older adults? Cross-sectional and prospective analyses. Alzheimer Disease & Associated Disorders. 2014 Oct–Dec;28(4):326–32. PMID 24614266. Not cognitive decline prevention intervention24614266
Young H, Benton D, Carter N. The effect of chicken extract on mood, cognition and heart rate variability. Nutrients. 2015;7(2):887–904. PMID 25642970. Inadequate follow up time25642970
Yu F, Bronas UG, Konety S, . Effects of aerobic exercise on cognition and hippocampal volume in Alzheimer’s disease: study protocol of a randomized controlled trial (The FIT-AD trial). Trials [Electronic Resource]. 2014;15:394. PMID 25304364. Ineligible population25304364
Yu F, Nelson NW, Savik K, . Affecting Cognition and Quality of Life via Aerobic Exercise in Alzheimer’s Disease. Western Journal of Nursing Research. 2013 January;35(1):24–38. PMID 21911546. Ineligible population21911546
Yu F, Ryan LH, Schaie KW, . Factors associated with cognition in adults: the Seattle Longitudinal Study. Research in Nursing & Health. 2009 Oct;32(5):540–50. PMID 19606423. No relevant outcomes reported19606423
Yu F, Savik K, Wyman JF, . Maintaining physical fitness and function in Alzheimer’s disease: a pilot study. American Journal of Alzheimer’s Disease & Other Dementias. 2011 Aug;26(5):406–12. PMID 21750046. Ineligible population21750046
Yu F, Thomas W, Nelson NW, . Impact of 6-month aerobic exercise on Alzheimer’s symptoms. Journal of Applied Gerontology. 2015 04 Jun;34(4):484–500. PMID 2015097557. Ineligible population24652914
Yu L, Lin SM, Zhou RQ, . Chinese herbal medicine for patients with mild to moderate Alzheimer disease based on syndrome differentiation: A randomized controlled trial. Journal of Chinese Integrative Medicine. 2012 July;10(7):766–76. PMID 2012439210. Ineligible population22805083
Yu L, Shulman JM, Chibnik L, . The CETP I405V polymorphism is associated with an increased risk of Alzheimer’s disease. Aging Cell. 2012 Apr;11(2):228–33. PMID 22122979. Ineligible study design22122979
Yu W, Chen Y, Wang S, . Cataract surgery is associated with a reduced risk of dementia: A nationwide population-based cohort study. European Journal of Neurology. 2015 Oct;22(10):1370–9. PMID 2014-37655-001. Ineligible study design25196252
Yu WK, Chen YT, Wang SJ, . Cataract surgery is associated with a reduced risk of dementia: A nationwide population-based cohort study. European Journal of Neurology. 2015 01 Oct;22(10):1370–e80. PMID 2014941288. Ineligible study design25196252
Zanchetti A, Liu L, Mancia G, . Blood pressure and LDL-cholesterol targets for prevention of recurrent strokes and cognitive decline in the hypertensive patient: Design of the European Society of Hypertension-Chinese Hypertension League Stroke in Hypertension Optimal Treatment randomized trial. Journal of Hypertension. 2014 September;32(9):1888–97. PMID 2014544821. Ineligible population24979303
Zaninotto AL, Bueno OF, Pradella-Hallinan M, . Acute cognitive effects of donepezil in young, healthy volunteers. Human Psychopharmacology. 2009 Aug;24(6):453–64. PMID 19637397. Inadequate follow up time19637397
Zeidan F, Johnson SK, Diamond BJ, . Mindfulness meditation improves cognition: evidence of brief mental training. Consciousness & Cognition. 2010 Jun;19(2):597–605. PMID 20363650. Inadequate follow up time20363650
Zelinski EM, Peters KD, Hindin S, . Evaluating the relationship between change in performance on training tasks and on untrained outcomes. Frontiers in human neuroscience. 2014;8:617. Inadequate follow up time25165440
Zelinski EM, Spina LM, Yaffe K, . Improvement in memory with plasticity-based adaptive cognitive training: results of the 3-month follow-up. Journal of the American Geriatrics Society. 2011 Feb;59(2):258–65. PMID 21314646. Inadequate follow up time21314646
Zhang N, Wei C, Du H, . The Effect of Memantine on Cognitive Function and Behavioral and Psychological Symptoms in Mild-to-Moderate Alzheimer’s Disease Patients. Dementia and Geriatric Cognitive Disorders. 2015 22 Jul;40(1–2):85–93. PMID 2015126070. Ineligible population26066622
Zhang X, Ni X, Chen P. Study about the effects of different fitness sports on cognitive function and emotion of the aged. Cell Biochemistry & Biophysics. 2014 Dec;70(3):1591–6. PMID 24997050. Cohort study with inadequate sample size24997050
Zhao MX, Dong ZH, Yu ZH, . Effects of Ginkgo biloba extract in improving episodic memory of patients with mild cognitive impairment: A randomized controlled trial. Journal of Chinese Integrative Medicine. 2012 June;10(6):628–34. PMID 2012376956. Not available in English22704410
Zhao Q, Lee JH, Pang D, . Estrogen receptor-Beta variants are associated with increased risk of Alzheimer’s disease in women with down syndrome. Dementia & Geriatric Cognitive Disorders. 2011;32(4):241–9. PMID 22156442. Cohort study with inadequate sample size22156442
Zhao X, Zhou R, Fu L. Working memory updating function training influenced brain activity. PLoS ONE [Electronic Resource]. 2013;8(8):e71063. PMID 24015182. No relevant outcomes reported24015182
Zhao Y, Navia BA, Marra CM, . Memantine for AIDS dementia complex: open-label report of ACTG 301. HIV Clinical Trials. 2010 Jan–Feb;11(1):59–67. PMID 20400412. Inadequate follow up time20400412
Zheng Z, Zhu X, Yin S, . Combined cognitive-psychological-physical intervention induces reorganization of intrinsic functional brain architecture in older adults. Neural Plasticity. 2015;2015:713104. PMID 25810927. Inadequate follow up time25810927
Zhitkova JV. Comparison of different doses of escitalopram in the prevention of dementia in patients with depression and moderate cognitive dysfunction associated with chronic brain ischemia. [Russian]. Zhurnal Nevrologii i Psihiatrii imeni S.S. 2015;Korsakova. 2015(8):53–60. PMID 609429789. Not available in English
Zhong Y, Miao Y, Jia WP, . Hyperinsulinemia, insulin resistance and cognitive decline in older cohort. Biomedical & Environmental Sciences. 2012 Feb;25(1):8–14. PMID 22424621. Cohort study with inadequate sample size22424621
Zhong Y, Zheng X, Miao Y, . Effect of CYP2D6 10 and APOE polymorphisms on the efficacy of donepezil in patients with Alzheimer’s disease. American Journal of the Medical Sciences. 2013 Mar;345(3):222–6. PMID 22986607. Ineligible population22986607
Zhuang JP, Fang R, Feng X, . The impact of human-computer interaction-based comprehensive training on the cognitive functions of cognitive impairment elderly individuals in a nursing home. Journal of Alzheimer’s Disease. 2013;36(2):245–51. PMID 23587747. Ineligible population23587747
Ziemann U, Siebner HR. Inter-subject and inter-session variability of plasticity induction by non-invasive brain stimulation: Boon or bane? Brain Stimulation. 2015 May;8(3):662–3. PMID 2015-26434-013. Ineligible study design25704341
Zieschang T, Schwenk M, Oster P, . Sustainability of motor training effects in older people with dementia. Journal of Alzheimer’s Disease. 2013;34(1):191–202. PMID 23202438. Ineligible population23202438
Zimmermann N, Netto TM, Amodeo MT, . Working memory training and poetry-based stimulation programs: are there differences in cognitive outcome in healthy older adults? Neurorehabilitation. 2014;35(1):159–70. PMID 24990015. Inadequate follow up time24990015
Zlatic CO, Mao Y, Ryan TM, . FluphenazineHCl and Epigallocatechin Gallate Modulate the Rate of Formation and Structural Properties of Apolipoprotein C-II Amyloid Fibrils. Biochemistry. 2015 Jun 23;54(24):3831–8. PMID 26021642. Ineligible study design26021642