# Appendix C Cognitive Performance Outcomes

Appendix Table C1 Cognitive outcomes categorization

Test Names | Common Abbreviations | Cognitive Outcome Categorization
Abstraction (Shipley Inst. of Living Scales subtest) | | Executive/Attention/Processing Speed
AD Cooperative StudiesAD Assessment Scale - Cognitive Subscale | ADAS-Cog, ADCS-Cog | Multidomain Neuropsychological Test Performance
AD Cooperative Studies ADL in MCI Scale | ADCS-MCI-ADL | Multidomain Neuropsychological Test Performance
AD Cooperative Studies Activities of Daily Living Scale | ADCS-ADL | Multidomain Neuropsychological Test Performance
Babcock Story Recall | | Memory
Benton Visual Retention Test | BVRT | Memory
Blessed Dementia Rating Scale: Blessed Information Memory Concentration | BIMC | Brief Cognitive Test Performance
Blessed Dementia Rating Scale: Blessed Rating Scale | BRS, DRS, BDS, Dementia score | Brief Cognitive Test Performance
Block Design (WAIS subtest) | BD | Visuospatial
Boston Naming Test - multiple versions: 15, 30, 60-items | BNT | Language
Brief Visuospatial Memory Test | BVMT, BVMT-R | Memory
Brixton Spatial Anticipation Test | Brixton | Executive/Attention/Processing Speed
Buschke Selective Reminding Test | SRT | Memory
California Verbal Learning Test - multiple versions | CVLT, CVLT-II | Memory
Cancellation Tests (several versions: bell, star, letter, ...) | | Visuospatial
Cambridge Neuropsychological Test Automated Battery (part of the CAMDEX) | CANTAB | Multidomain Neuropsychological Test Performance
CERAD word list / list learning subtest | CERAD | Memory
Clock Drawing Tests (many versions & featured in screening tools) | CDT, CLOX | Visuospatial
Cognitive Abilities Screening Instrument | CASI | Brief Cognitive Test Performance
Consortium to Establish a Registry for Alzheimer’s Disease (cognitive battery) | CERAD | Multidomain Neuropsychological Test Performance
Continuous Performance Test | CPT | Executive/Attention/Processing Speed
Corsi Block Tapping - fowards & backwards (similar to Spatial Span) | | Executive/Attention/Processing Speed
Delis–Kaplan Executive Function System | D-KEFS | Executive/Attention/Processing Speed
Digit Span - forwards & backwards (WAIS/WMS subtest) | DS, DSp | Executive/Attention/Processing Speed
Digit Symbol Coding (WAIS subtest; inverse of Symbol Digit Modalities) | DSy | Executive/Attention/Processing Speed
East Boston Story or East Boston Memory Test | EBMT | Memory
Faces - parts I & II (WMS subtest) | | Memory
Finger Tapping Test | FTT | Motor
Grip Strength / Hand Dynamometer | | Motor
Grooved Pegboard | | Motor
Hopkins Verbal Learning Test | HVLT, HVLT-R | Memory
Judgement of Line Orientation | JLO | Visuospatial
Letter Digit Substitution (Coding) Test | LDST | Executive/Attention/Processing Speed
Letter-Number Sequencing (most commonly a WAIS subtest) | LNS | Executive/Attention/Processing Speed
Letter Sets | | Executive/Attention/Processing Speed
Logical Memory - parts I & II (WMS subtest) | LM, LMI, LMII | Memory
Matrix Reasoning (WAIS subtest) | | Executive/Attention/Processing Speed
Mattis Dementia Rating Scale | MDRS, DRS | Multidomain Neuropsychological Test Performance
Maze Tracing (including Porteus Maze Test) | | Executive/Attention/Processing Speed
Mini-Mental State Examination | MMSE | Brief Cognitive Test Performance
Modified Mini-Mental State Examination | 3MS, 3MSE | Brief Cognitive Test Performance
Montreal Cognitive Assessment | MoCA | Brief Cognitive Test Performance
N-Back | | Executive/Attention/Processing Speed
National Adult Reading Test | NART | Language
Neurobehavioral Cognitive Status Examination (original Cognistat paper test) | NCSE | Multidomain Neuropsychological Test Performance
New York University Paragraph Recall | | Memory
Number Series | | Executive/Attention/Processing Speed
Picture Completion (many versions, most commonly a WAIS subtest) | PC | Executive/Attention/Processing Speed; Visualspatial
Purdue Pegboard | PPT, PPBT | Motor
Raven’s Progressive Matrices (several versions including Colored & Advanced) | RPM, RCPM | Executive/Attention/Processing Speed
Reaction Time Tests (many versions: simple, choice, auditory, visual...) | RT, SRT | Executive/Attention/Processing Speed
Repeatable Battery for the Assessment of Neuropsychological Status | RBANS | Multidomain Neuropsychological Test Performance
Rey Auditory Verbal Learning Test | RAVLT (may see AVLT or RVLT) | Memory
Rey-Osterrieth Complex Figure Test | CFT, RCFT, Rey-O, Rey | Memory; Visuospatial
Rivermead Behavioral Memory Test - multiple versions | RBMT, RBMT-II, RBMT-3 | Memory
Self-Ordered Pointing Task(Test) | SOPT | Executive/Attention/Processing Speed
Short Portable Mental Status Questionnaire | SPMSQ | Brief Cognitive Test Performance
Short Test of Mental Status | STMS | Brief Cognitive Test Performance
Syndrom Kurztest - SKT (German) | SKT | Executive/Attention/Processing Speed; Memory
Spatial Span - forwards & backwards (WMS subtest; similar to Corsi Block Tapping) | | Executive/Attention/Processing Speed
Stroop - color, word, interference (there aremanyversions of the Stroop) | | Executive/Attention/Processing Speed
Symbol Digit Modalities Test (inverse of Digit Symbol) | SDMT | Executive/Attention/Processing Speed
Taylor Complex Figure | | Memory; Visuospatial
Telephone Interview for Cognitive Status | TICS | Brief cognitive test performance
Telephone Interview for Cognitive Status, modified | TICS-M, mTICS | Brief cognitive test performance
Token Test | | Language
Trail Making Test - part A | TMT A | Executive/Attention/Processing Speed
Trail Making Test - part B (orB-A, B/A, etc.) | TMT B | Executive/Attention/Processing Speed
Verbal Fluency, Phonemic/Phonological or Letter | VF, PVF, FAS, CFL, COWAT, COWA | Executive/Attention/Processing Speed; Language
Verbal Fluency, Semantic or Category | VF, SVF, animals, names, fruits/vegetables | Language
Visual Reproduction (WMS subtest) | VR, VRI, VRII, Vis Rep | Memory
Useful Field of View | UFOV | Executive/Attention/Processing Speed
Walter Reed performance assessment battery | | Multidomain Neuropsychological Test Performance
Wechsler Adult Intelligence Scale - multiple versions | WAIS, WAIS-R, WAIS-III, WAIS-IV | Multidomain Neuropsychological Test Performance
Wechsler Memory Scale - multiple versions | WMS, WMS-R, WMS-III, WMS-IV | Memory
Wisconsin Card Sorting Test | WCST | Executive/Attention/Processing Speed

Appendix Table C2 Neuropsychological tests and reliable change indices

Cognitive Domain | Instrument | Measurement Properties | Reliable Change Indices
Global Cognitive Function | Alzheimer’s Disease Assessment Scale-Cognitive subscale (ADAS-Cog) | Used to measure cognitive impairment in the assessment of Alzheimer’s disease. Tests several cognitive domains, including memory, language, and praxis. Range: 0–70; higher scores indicate worse cognition^17^ | 4 pts (6 months); considered to be clinically important, but not meaningful; no established RCI’s^17^
Global Cognitive Function | Mini-Mental State Examination (MMSE) | 11 items assessing cognitive function: orientation, registration, attention and calculation, recall, language (range 0–30) Range: 0–30; higher scores indicate better^18^ | 2.73 pts (3 months) 3.60 pts (5 years)^19^
Global Cognitive Function | Modified Mini-Mental State Examination (3MS) | 15 items: 11 from MMSE plus 4 additional items assessing long-term memory, abstract thinking, category fluency, delayed recall Range: 0–100; higher scores indicate better cognition^18^ | 5 pts ^20^ 7.41 pts (3 months) 9.82 pts (5 years)^19^
Global Cognitive Function | Telephone Interview for Cognitive Status (TICS) | 11 items assessing word list memory, orientation, attention, repetition, conceptual knowledge, nonverbal praxis Range: 0–41; higher scores indicate better cognition^18^ | None identified
Executive, Attention, Processing Speed | Tower Test | Varying number of items assessing spatial planning, rule learning, inhibition of impulsive and perseverative responding, and the ability to establish and maintain instructional set. Subjects must construct towers using 5 circular pieces, placed onto one of 3 pegs. Towers constructed must be identical to a picture shown. Subjects are not allowed to place a larger piece on a smaller piece, and must move one piece at a time. Range: 0–30^21^ | None identified
Executive, Attention, Processing Speed | Digit Span Forward^*†^ | Varying number of items assessing attention efficiency and capacity: subjects asked to listen to a sequence of numbers read and then recite back in order (reported as either subscore or summary score with Digit Span Backward) | None identified; part of WAIS-III WMI and VIQ
Executive, Attention, Processing Speed | Digit Span Backward^*†^ | Varying number of items assessing executive function and especially working memory: sequence of numbers read, participants asked to read sequence back in reverse order (reported as either subscore or summary score with Digit Span Forward) | None identified; part of WAIS-III WMI and VIQ
Executive, Attention, Processing Speed | Digit Symbol Substitution Test^*^ | Varying number of items assessing psychomotor ability, sustained attention, processing speed and working memory: participants asked to use a key to substitute certain items within rows of numbers (Digit Symbol) or symbols (Symbol Digit Modalities) (score comprised of items completed within the specified time). | None identified; part of WAIS-III PSI and PIQ
Executive, Attention, Processing Speed | Stroop Interference Test | 3 to 4 parts (depending on the version). Original version has 4 parts. Part 1: rows of written color names written in black ink, and the subject must say the written word. Part 2: the subject reads color names printed in colored ink, ignoring the printed color. Part 3: Subject names the colors of squares. Part 4: the subject uses the printed words from part 2, but must say the color of the ink each word is printed in instead of saying the word. Range: Time to completion and number of errors. Higher raw time and raw errors indicate worse cognition.^18^ | None identified
Executive, Attention, Processing Speed | Trail Making Test Part A (Trails A) | Assesses visual attention and processing speed: subject asked to draw lines connecting circled numbers in sequence (score comprised of both time to complete task and number of errors made; higher score indicates lower function, unless age-scaled score is presented) Range: Time, in seconds, required for completion; higher raw scores indicate worse cognition while higher scaled scores indicate better cognition. Additionally, if error rate is reported, then higher error rates indicate worse cognition.^18^ | Scores to calculate RCI: T2-T1 mean, SD: −0.96, 7.54^22^
Executive, Attention, Processing Speed | Vigil/Continuous Performance Task (CPT) | Varying number of items assessing sustained and selective attention. Letters flash by one at a time on a computer screen. Subject must press the spacebar after they see an ‘A’ followed immediately by a ‘K.^18^ | None identified
Executive, Attention, Processing Speed | Wisconsin Card Sorting Test (WCST) | Cards are presented to the subject. Subject is told to match the cards, but not how to match; however, he or she is told whether a particular match is right or wrong.^18^ | None identified
Intelligence Quotient (Verbal Comprehension, Perceptual Reasoning, Working Memory, Processing Speed) | Wechsler Adult Intelligence Scale (WAIS) | Published battery of neuropsychological tests with varying numbers of core and optional subtests. WAIS-III assesses Verbal Comprehension (Similarities, Vocabulary, Information); Working Memory (Digit Span, Arithmetic, [Letter-Number Sequencing], [Comprehension]); Perceptual Organization (Picture Completion, Block Design, Matrix Reasoning); and Processing Speed (Digit Symbol, [Symbol Search], [Picture Arrangement], [Object Assembly]). [Bracketed] subtests are optional.^18^ | VIQ: 9 pts PIQ: 11 pts FSIQ: 9 pts VCI: 11 pts POI: 13 pts WMI: 1 2pts PSI: 14 pts (WAIS-III)^23^
Memory | Wechsler Memory Scale (WMS) | Published battery of neuropsychological tests with varying numbers of core and optional tests. WMS-III assesses auditory presentation (Logical Memory I and II, Verbal Paired Associates I and II, [Letter-Number Sequencing], [Information and Orientation], [Word Lists I and II], [Mental Control], [Digit Span]) and visual presentation (Faces I and II, Family Pictures I and II, [Spatial Span], [Visual Reproduction I and II]).^18^ | None identified
| Benton Visual Retention Test (BVRT) | 10 items (designs) assessing visual memory and perception: subjects are shown one design at a time and asked to draw it from memory (score based on either correctness of drawing or number of errors made; higher error scores indicate lower function) Range: 0–10; higher scores indicate better cognition^18^ | None identified
| Rey-Osterrich Complex Figure | 3 part test assessing visuospatial abilities, memory, attention, planning, and working memory (executive functions). Subject asked to reproduce a complicated line drawing 3 times: first by copying it while looking at the figure, second by reproducing it immediately afterwards from memory, and third by reproducing the figure again after a 20 to 30-minute delay^18^ | Scores to calculate RCI: Copy T2-T1 mean, SD: −0.03, 1.76 Immediate Recall T2-T1 mean, SD: 2.48, 4.51 Delayed Recall T2-T1 mean, SD: 2.30, 4.32^24^
| Buschke Selective Reminding Test | 12 items in one list assessing verbal recall and recognition, with a possible 12 trials. List is read aloud until subject recalls all 12 words three times in a row, or until items are read 12 total times (whichever occurs first). After a 20 to 30-minute delay, subjects are asked to recall the 12 words again. Then a recognition trial may be given, which consists of a longer list of words that is read one word at a time; subjects respond ‘yes’ or ‘no’ if the word was on the original list of 12. Range: 0–12 for each trial and the recognition score, with higher scores indicating better cognition. Also an intrusion score for the recognition portion, counting each incorrect ‘yes’ given; higher scores indicate worse cognition^18^ | None identified
| California Verbal Learning Test (CVLT) | 32 items in two lists (A & B) of 16 words assessing verbal recall and recognition: List A is presented five times for learning and List B is presented once as a distractor Range: Total Recall Score is 20–80; all other scores are z-scores -5 to +5; higher error and recency-recall index scores indicate worse cognition; all other higher scores indicate better cognition^18^ | None identified
| Rey Auditory Verbal Learning Test (RAVLT) | 30 items in two lists assessing verbal recall and recognition. First a list of 15 words is read aloud and subjects are asked to recall as many as possible (over 5 trials, with the list repeated each time). Then subjects are read a 15 word distractor list and asked to recall as many of the distractor words as possible (1 trial). Afterwards subjects are asked to recall as many of the original 15 words as possible (without being read the list). After a 20-minute delay period, subjects are asked to recall the original list of 15-words again (1 trial). Then a recognition trial may be given, which consists of a longer list of words that is read one word at a time; subjects respond ‘yes’ or ‘no’ if the word was on the original list of 15. Range: 0–15 for each trial (1–5, the distractor, delayed recall, and recognition) with higher scores indicating better cognition. Also an intrusion score for the recognition portion, counting each incorrect ‘yes’ given; higher scores indicate worse cognition.^18^ | (decline; improvement) Trial 1:−2.77; 2.65 Trial 5: −3.51; 2.63 Sum 1–5: −11.64; 9.36 Interference: −3.03; 3.11 Trial 7: −4.73; 3.57 Delay: −4.96; 3.60 Recognition: −3.47; 3.69 (12 months)^25^
| Wechsler Adult Intelligence Scale (WAIS) | Published battery of neuropsychological tests with varying numbers of core and optional subtests. WAIS-III assesses Verbal Comprehension (Similarities, Vocabulary, Information); Working Memory (Digit Span, Arithmetic, [Letter-Number Sequencing], [Comprehension]); Perceptual Organization (Picture Completion, Block Design, Matrix Reasoning); and Processing Speed (Digit Symbol, [Symbol Search], [Picture Arrangement], [Object Assembly]). [Bracketed] subtests are optional.^18^ | VIQ: 9 pts PIQ: 11 pts FSIQ: 9 pts VCI: 11 pts POI: 13 pts WMI: 1 2pts PSI: 14 pts (WAIS-III)^23^
Language | Boston Naming Test (BNT) | 60 items assessing word retrieval. Subjects are shown pictures and asked to name what they are pictures of, and receive semantic cues if needed Range: 0–60; higher scores indicate better cognition^18^ | 4 pts (9–15 months); 6 pts (16–24 months)Sachs, 2012 #618}
Language | Verbal Fluency Test | Varying number of items assessing spontaneous verbal production: subjects asked to produce as many words beginning with a specific letter (phonemic/letter fluency) or as many words in a specific category such as “animals” (semantic/category fluency) as is possible in one minute Range (phonemic fluency): sum of all admissible words for the three letters; higher scores indicate better cognition Range (semantic fluency): sum of all admissible words for the semantic categories; higher scores indicate better cognition^18^ | (Decline; improvement) Letter ‘S’: −5.5; 9.8 Animals: −7.6; 10.5 (1 month)^26^

^*^ Subtest of WAIS;

^†^ Subtest of WMS

Abbreviations: 3MS=Modified Mini-Mental State Examination; BNT=Boston Naming Test; BVRT=Benton Visual Retention Test; CERAD=Consortium to Establish a Registry for Alzheimer’s Disease; CPT=Continuous Performance Task; CVLT=California Verbal Learning Test; DKEFS=Delis-Kaplan Executive Function System; FSIQ=Full Scale IQ; MMSE=Mini-Mental State Examination; PIQ=Performance IQ; POI=Perceptual Organization Index; PSI=Processing Speed Index; RCI=Reliable Change Index; RVLT=Rey Verbal Learning Test; SDMT=Symbol Digit Modalities Test; TICS=Telephone Interview for Cognitive Status; Trails A= Trail Making Test Part A; Trails B=Trail Making Test Part B; VCI=Verbal Comprehension Index; VIQ=Verbal IQ; WAIS=Wechsler Adult Intelligence Scale; WMI=Working Memory Index; WMS=Wechsler Memory Scale