# Appendix B Risk of Bias Assessment Tool

Review the methods of each trial and assess each risk of bias component as described in these instructions. You may need to have separate assessments for different outcomes (i.e. different measures; different time points may have different attrition rates). Remember, this tool is not an algorithm. Discretion must be applied.

## 1 Selection Bias

Systematic differences between baseline characteristics of the groups that arise from self-selection of treatments, physician-directed selection of treatments, or association of treatment assignments with demographic, clinical, or social characteristics.

- Did method of randomization create biased allocation to interventions (inadequate randomization)?
- “Good” Randomization: Random numbers table, computer random number generator
- “Poor” Randomization: Randomized based on week of the month of birthday
- No Randomization: Non-randomized clinical trial, observational study

Figure B1 Risk of bias: Selection bias

This figure displays a guide for determining selection bias. Studies with good randomization are rated low for selection bias. Studies with poor randomization or no randomization are rated medium for selection bias, but with systematic assignment. Those studies without systematic assignment are rated high for selection bias, unless they have made an appropriate adjustment (e.g., propensity score, multivariate analysis) to address the potential risk of selection bias.

## 2 Attrition

Systematic differences in the loss of participants from the study and how they were accounted for in the results (e.g., incomplete followup, differential attrition). Those who drop out of the study or who are lost to followup may be systematically different from those who remain in the study. Attrition bias can potentially change the collective (group) characteristics of the relevant groups and their observed outcomes in ways that affect study results by confounding and spurious associations.

- Reasons for incomplete/missing data adequately explained?
- Do the author’s attempt to address attrition in the analysis?

Figure B2 Risk of bias: Attrition

This figure displays a guide for determining attrition bias. Studies could receive a rating of low attrition bias if the attrition rate was less than 10% or between 10% and 20% if there was an appropriate analysis to address potential bias. Studies with an attrition rate between 10% and 20% without any analysis to address attrition received a rating of medium attrition bias. Studies with an attrition rate between 21% and 40% received an attrition rate of medium if there was an appropriate analysis to address potential bias. Studies without an appropriate analysis received a rating of high risk of attrition bias. Studies with an attrition rate greater than 40% were assessed as having a high risk of attrition bias.

### Notes

- Report attrition rate in spreadsheet.
- If a study reports outcomes at multiple intervals (e.g., 6 months, 12 months, 18 months) assess attrition at each time-point and record separately.
- Analysis should be done with appropriate method (i.e., sensitivity analysis with various scenarios; last value forward would only be appropriate for interventions that are supposed to improve the outcomes (i.e., memory training that intends to improve memory).

## 3 Selection and Attrition Bias Overall

Assess joint selection and attrition bias. If either selection or attrition bias is high, the risk of bias is HIGH.

Table B1 Selection and attrition bias overall

Selection Bias | Low | Low | Medium | Low | Medium | Medium | High
Attrition Bias | Low | Medium | Low | High | Medium | High | X
Action | Assess other biases | Assess other biases | Assess other biases | STOP | Assess other biases | STOP | STOP

## 4 Other Biases

### A Detection Bias

Systematic differences in outcomes assessment among groups being compared, including systematic misclassification of the exposure or intervention, covariates, or outcomes because of variable definitions and timings, diagnostic thresholds, recall from memory, inadequate assessor blinding, and faulty measurement techniques. Erroneous statistical analysis might also affect the validity of effect estimates.

- Were the outcome assessors blinded to the intervention (“outcome assessor blinded”)?
- Was the timing of the outcome assessment similar in all groups (“comparable timing outcomes assessment”)?
- Was the scale used to measure outcomes validated, reliable?
- Were outcomes measured in clinically meaningful ways?

Table B2 Detection bias

Domain | Options | | Overall Rating
Outcome assessor blinded | Yes | No | All 4 Yes =Low 2 or 3 Yes = Medium 3+ No=High
Outcome assessor independent | Yes | No | All 4 Yes =Low 2 or 3 Yes = Medium 3+ No=High
Comparable timing outcomes assessment | Yes | No | All 4 Yes =Low 2 or 3 Yes = Medium 3+ No=High
Outcome assessment instrument/measurement quality | Yes (Adequate) | No (Inadequate) | All 4 Yes =Low 2 or 3 Yes = Medium 3+ No=High

### B Performance Bias

Systematic differences in the care provided to participants and protocol deviation. Examples include contamination of the control group with the exposure or intervention, unbalanced provision of additional interventions or co-interventions, difference in co-interventions, and inadequate blinding of providers and participants.

#### Notes

- Intention-to-Treat (ITT): Includes every subject according to randomized treatment assignment. Ignores noncompliance, protocol deviations, withdrawal, and anything that happens after randomization.
- Concurrent Intervention: Study participants are receiving another intervention (i.e., treatment) that is not part of the intervention being tested. Example: Participants are randomized to a physical activity intervention (or no intervention), but are also dieting.

Table B3 Performance bias

Domain | Options | Rating | Overall Rating
1a. RCTs-ITT | Yes | Low | Low All Low=Low 1-Low, 2-Low, 3-N/A=Low Medium 1-Low, 2-Low, 3-High=Medium 1-Low, 2-Medium, 3-Low=Medium 1-Low, 2-Medium, 3-N/A=Medium 1-Medium, 2-Medium, 3-N/A=Medium 1-Medium, 2-High, 3-Low=Medium 1-Medium, 2-Medium, 3-High=Medium High 1-High + Anything Else=High 2+ High=High
1a. RCTs-ITT | No/Not reported | High
1b. Obs-Adjustment for known confounders | Adequate | Low
1b. Obs-Adjustment for known confounders | Inadequate | High
2. Concurrent intervention | Yes-Adjusted | Medium
2. Concurrent intervention | Yes-Unadjusted | High
2. Concurrent intervention | No | Low
2. Concurrent intervention | Unclear/Not Reported | NR
3. Participant Blinding | Yes | Low
3. Participant Blinding | No | Medium
3. Participant Blinding | N/A | N/A

### C Reporting Bias

Systematic differences between reported and unreported findings (e.g., differential reporting of outcomes or harms, incomplete reporting of study findings, potential for bias in reporting through source of funding).

- Was a select group of outcomes reported?

#### Notes

- Compare results to methods section and/or protocol.
- Check if some results are reported in a different publication.

Table B4 Reporting bias

Domain | Options | Rating
All outcomes reported | Yes | Low
All outcomes reported | No | Medium
All outcomes reported | Not Reported | Medium

## 5 Overall Rob

Figure B5 Overall risk of bias

This figure displays a guide for determining overall risk of bias. Studies could only receive an overall risk of bias rating of low if both selection and attrition bias were rated low and all other biases were rated low or a mix of medium and low. Studies with either high selection and/or attrition bias were rated high risk of bias. Studies with low or medium selection bias, medium attrition bias, and at least one other bias rated as high were rated high risk of bias. Studies with medium selection bias, low or medium attrition bias, and at least one other bias rated as high were rated as high risk of bias. Studies with medium selection and attrition bias and any other bias rated as high were rated as high risk of bias. All other combinations of domain biases were rated as medium risk of bias.