# Appendix A Search Strategies

## Database: Ovid MEDLINE(R) Search Strategy: RCTs

1 | exp Tertiary Prevention/ or exp Secondary Prevention/ or exp Primary Prevention/ (141964)
2 | prevent*.ti. (216549)
3 | protect*.ti. (118660)
4 | delay*.ti. (51184)
5 | ((reduc* or decreas* or effect* or lower* or modif* or change* or stop* or improv* or increas* or enhanc* or rais*) and risk*).ti. (43135)
6 | 1 or 2 or 3 or 4 or 5 (545854)
7 | lifestyle*.ti. (8489)
8 | life style.ti. (1355)
9 | exp Health Behavior/ (133222)
10 | exp Motor Activity/ (216634)
11 | ((physical or aerobic* or leisure) and (activit* or fitness)).ti. (25122)
12 | exercis*.ti. (84377)
13 | exp Diet/ (218815)
14 | diet*.ti. (134912)
15 | fruit*.ti. (16048)
16 | vegetable*.ti. (7963)
17 | nutrition*.ti. (74518)
18 | fat*.ti. (181033)
19 | caffeine.ti. (9030)
20 | sodium.ti. (73002)
21 | salt*.ti. (34028)
22 | alcohol*.ti. (103760)
23 | ((smok* or tobacco) and (quit or cessation or stop*)).ti. (9709)
24 | ((metacognitive or cognitive or mental or brain or memory or social or perceptual or computer) and (activit* or train* or stimulat* or intervention or engag* or rehab*)).ti. (36862)
25 | exp *Pharmacology, Clinical/ (1700)
26 | exp Pharmaceutical Preparations/ (674904)
27 | drug*.ti. (298706)
28 | medication*.ti. (29416)
29 | pharmacopsychiatry.ti. (51)
30 | exp Psychopharmacology/ (5429)
31 | lovastatin/ or simvastatin/ or pravastatin/ (11705)
32 | statin*.ti. (9993)
33 | exp Antihypertensive Agents/ (234730)
34 | anti-hypertensive*.ti. (541)
35 | antihypertensive*.ti. (10665)
36 | exp Cholinesterase Inhibitors/ (44525)
37 | Acetylcholinesterase inhibitor*.ti. (815)
38 | (Donepezil or Aricept or Memantine or Namenda or Rivastigmine or Exelon or Galantamine or razadyne or Quetiapine or seroquel).ti. (4354)
39 | cholinesterase inhibitor*.ti. (1161)
40 | exp Antibodies, Monoclonal/ or exp Antibodies, Monoclonal, Humanized/ (190958)
41 | anti amyloid*.ti. (125)
42 | antiamyloid*.ti. (26)
43 | Solanezumab.ti. (15)
44 | crenezumab.ti. (0)
45 | gantenerumab.ti. (6)
46 | crenezumab.ab. (4)
47 | antiplatlet.ti. (0)
48 | anti-platelet.ti. (782)
49 | (Triflusal or Ticlid or plavix or brilinta or persantine or Ticlopidine or Dipyridomole or Clopidogrel).ti. (4606)
50 | exp Hypoglycemic Agents/ (206876)
51 | (Pioglitazone or actos or Glucophage or metformin).ti. (6739)
52 | ((gonadal or sex) adj steroid*).ti. (3910)
53 | exp Hormone Replacement Therapy/ (21950)
54 | estrogen*.ti. (46056)
55 | progest*.ti. (27523)
56 | medroxyprogesterone*.ti. (1983)
57 | estradiol.ti. (17656)
58 | raloxifene.ti. (1169)
59 | exp Cyclooxygenase 2 Inhibitors/ (10161)
60 | (Celecoxib or Rofecoxib).ti. (2498)
61 | exp Anti-Inflammatory Agents, Non-Steroidal/ (170835)
62 | (Ibuprofen or Tarenflurbil or flurbiprofen or Flurizan or Naproxen or Aspirin).ti. (19958)
63 | exp Dietary Supplements/ (49171)
64 | supplement*.ti. (42004)
65 | nutraceutical*.ti. (625)
66 | exp Nootropic Agents/ (28153)
67 | nootropic*.ti. (444)
68 | exp Vitamins/ (279374)
69 | exp Minerals/ (129537)
70 | omega.ti. (7082)
71 | ginkgo biloba.ti. (1700)
72 | ginko biloba.ti. (6)
73 | folate.ti. (7866)
74 | fish oil.ti. (2892)
75 | saffron.ti. (288)
76 | crocus sativus.ti. (206)
77 | fuzhisan.ti. (7)
78 | melissa.ti. (155)
79 | beta carotene.ti. (2945)
80 | vitamin*.ti. (79987)
81 | ((manag* or control* or lower* or reduc* or decreas* or loss or lose) and (weight or BMI or body mass index or overweight or obes* or diabetes or depress* or cardio* or vascular or blood pressure or hypertension or cholesterol or hypercholesterolemia or homocysteine)).ti. (84346)
82 | or/6–81 (3655158)
83 | dementia/ or alzheimer disease/ (104784)
84 | dement*.ti. (33084)
85 | exp Cognition/ (119536)
86 | exp Mild Cognitive Impairment/ or exp Cognition Disorders/ (68412)
87 | memory disorders/ (16505)
88 | executive funtion/ (0)
89 | exp memory/ (107625)
90 | cognition.ti. (7518)
91 | ((cognit* or neurocognit* or memory or neuropsy* or neuro*) adj (impair* or disorder* or dysfunction* or function* ag?ing or declin* or status or perform* or diabil* or disable* or maint* or enhanc*)).ti. (31889)
92 | ((maint* or impair* or disorder* or declin* or enhanc*) adj (cognit* or neurocognit* or memory or neuropsy* or neuro*)).ti. (1900)
93 | (amyloid or tau or plasticity).ti. (44515)
94 | ((brain or grey matter or gray matter) adj3 (function* or scan* or mri or volume or chang* or imag*)).ti. (15993)
95 | exp Biological Markers/ (681977)
96 | (83 or 86) and 95 (6502)
97 | 83 or 84 or 85 or 86 or 87 or 88 or 89 or 90 or 91 or 92 or 93 or 96 (403150)
98 | 82 and 97 (65610)
99 | *Alzheimer Disease/pc [Prevention & Control] (1256)
100 | *Mild Cognitive Impairment/pc [Prevention & Control] (48)
101 | Cognition Disorders/pc [Preventions & Control] (2341)
102 | or/98–101 (66756)
103 | 98 or 102 (66756)
104 | randomized controlled trials as topic/ (100210)
105 | randomized controlled trial/ (404260)
106 | random allocation/ (85128)
107 | double blind method/ (132506)
108 | single blind method/ (21176)
109 | clinical trial/ (495811)
110 | clinical trial, phase i.pt. (15460)
111 | clinical trial, phase ii.pt. (25039)
112 | clinical trial, phase iii.pt. (10500)
113 | clinical trial, phase iv.pt. (1099)
114 | controlled clinical trial.pt. (89967)
115 | randomized controlled trial.pt. (404260)
116 | multicenter study.pt. (192213)
117 | clinical trial.pt. (495811)
118 | exp Clinical trials as topic/ (286404)
119 | or/104–118 (1096584)
120 | (clinical adj trial$).tw. (219796)
121 | ((singl$ or doubl$ or treb$ or tripl$) adj (blind$3 or mask$3)).tw. (129617)
122 | placebos/ (32961)
123 | placebo$.tw. (159399)
124 | randomly allocated.tw. (17236)
125 | (allocated adj2 random$).tw. (19800)
126 | 120 or 121 or 122 or 123 or 124 or 125 (425064)
127 | 119 or 126 (1229155)
128 | 103 and 127 (13446)
129 | limit 128 to humans (12721)
130 | limit 129 to (addresses or autobiography or bibliography or biography or case reports or classical article or clinical conference or comment or congresses or consensus development conference or consensus development conference, nih or “corrected and republished article” or dataset or dictionary or directory or editorial or evaluation studies or historical article or in vitro or interactive tutorial or interview or lectures or legal cases or legislation or letter or news or newspaper article or observational study or patient education handout or periodical index or portraits or validation studies or video-audio media or webcasts) (838)
131 | 129 not 130 (11883)
132 | limit 131 to yr=“2009 -Current” (4830)

## Database: Ovid MEDLINE(R) Search Strategy: Observational Studies

Database: Ovid MEDLINE(R) <1946 to January Week 4 2016>
Search Strategy:
1 | exp Tertiary Prevention/ or exp Secondary Prevention/ or exp Primary Prevention/ (141964)
2 | prevent*.ti. (216549)
3 | protect*.ti. (118660)
4 | delay*.ti. (51184)
5 | ((reduc* or decreas* or effect* or lower* or modif* or change* or stop* or improv* or increas* or enhanc* or rais*) and risk*).ti. (43135)
6 | (biomarker* adj2 enrich*).ti. (11)
7 | intervention*.ti. (83501)
8 | program*.ti. (139255)
9 | multidomain*.ti. (421)
10 | multi-domain*.ti. (143)
11 | multicomponent*.ti. (1987)
12 | multi-component*.ti. (561)
13 | multifactoral*.ti. (15)
14 | multi-factoral*.ti. (2)
15 | approach*.ti. (175606)
16 | lifestyle*.ti. (8489)
17 | life style.ti. (1355)
18 | exp Health Behavior/ (133222)
19 | exp Motor Activity/ (216634)
20 | ((physical or aerobic* or leisure) and (activit* or fitness)).ti. (25122)
21 | exercis*.ti. (84377)
22 | exp Diet/ (218815)
23 | diet*.ti. (134912)
24 | fruit*.ti. (16048)
25 | vegetable*.ti. (7963)
26 | nutrition*.ti. (74518)
27 | fat*.ti. (181033)
28 | caffeine.ti. (9030)
29 | sodium.ti. (73002)
30 | salt*.ti. (34028)
31 | alcohol*.ti. (103760)
32 | ((smok* or tobacco) and (quit or cessation or stop*)).ti. (9709)
33 | ((metacognitive or cognitive or mental or brain or memory or social or perceptual or computer) and (activit* or train* or stimulat* or intervention or engag* or rehab*)).ti. (36862)
34 | exp *Pharmacology, Clinical/ (1700)
35 | exp Pharmaceutical Preparations/ (674904)
36 | drug*.ti. (298706)
37 | medication*.ti. (29416)
38 | pharmacopsychiatry.ti. (51)
39 | exp Psychopharmacology/ (5429)
40 | lovastatin/ or simvastatin/ or pravastatin/ (11705)
41 | statin*.ti. (9993)
42 | exp Antihypertensive Agents/ (234730)
43 | anti-hypertensive*.ti. (541)
44 | antihypertensive*.ti. (10665)
45 | exp Cholinesterase Inhibitors/ (44525)
46 | Acetylcholinesterase inhibitor*.ti. (815)
47 | (Donepezil or Aricept or Memantine or Namenda or Rivastigmine or Exelon or Galantamine or razadyne or Quetiapine or seroquel).ti. (4354)
48 | cholinesterase inhibitor*.ti. (1161)
49 | exp Antibodies, Monoclonal/ or exp Antibodies, Monoclonal, Humanized/ (190958)
50 | anti amyloid*.ti. (125)
51 | antiamyloid*.ti. (26)
52 | Solanezumab.ti. (15)
53 | crenezumab.ti. (0)
54 | gantenerumab.ti. (6)
55 | crenezumab.ab. (4)
56 | antiplatlet.ti. (0)
57 | anti-platelet.ti. (782)
58 | (Triflusal or Ticlid or plavix or brilinta or persantine or Ticlopidine or Dipyridomole or Clopidogrel).ti. (4606)
59 | exp Hypoglycemic Agents/ (206876)
60 | (Pioglitazone or actos or Glucophage or metformin).ti. (6739)
61 | ((gonadal or sex) adj steroid*).ti. (3910)
62 | exp Hormone Replacement Therapy/ (21950)
63 | estrogen*.ti. (46056)
64 | progest*.ti. (27523)
65 | medroxyprogesterone*.ti. (1983)
66 | estradiol.ti. (17656)
67 | raloxifene.ti. (1169)
68 | exp Cyclooxygenase 2 Inhibitors/ (10161)
69 | (Celecoxib or Rofecoxib).ti. (2498)
70 | exp Anti-Inflammatory Agents, Non-Steroidal/ (170835)
71 | (Ibuprofen or Tarenflurbil or flurbiprofen or Flurizan or Naproxen or Aspirin).ti. (19958)
72 | exp Dietary Supplements/ (49171)
73 | supplement*.ti. (42004)
74 | nutraceutical*.ti. (625)
75 | exp Nootropic Agents/ (28153)
76 | nootropic*.ti. (444)
77 | exp Vitamins/ (279374)
78 | exp Minerals/ (129537)
79 | omega.ti. (7082)
80 | ginkgo biloba.ti. (1700)
81 | ginko biloba.ti. (6)
82 | folate.ti. (7866)
83 | fish oil.ti. (2892)
84 | saffron.ti. (288)
85 | crocus sativus.ti. (206)
86 | fuzhisan.ti. (7)
87 | melissa.ti. (155)
88 | beta carotene.ti. (2945)
89 | vitamin*.ti. (79987)
90 | ((manag* or control* or lower* or reduc* or decreas* or loss or lose) and (weight or BMI or body mass index or overweight or obes* or diabetes or depress* or cardio* or vascular or blood pressure or hypertension or cholesterol or hypercholesterolemia or homocysteine)).ti. (84346)
91 | or/1–90 (3967512)
92 | dementia/ or alzheimer disease/ (104784)
93 | dement*.ti. (33084)
94 | exp Mild Cognitive Impairment/ or exp Cognition Disorders/ (68412)
95 | ((cognit* or neurocognit* or memory or neuropsy* or neuro*) adj (impair* or disorder* or dysfunction* or diabil* or disable*)).ti. (23706)
96 | ((impair* or disorder*) adj (cognit* or neurocognit* or memory)).ti. (576)
97 | or/92–96 (175046)
98 | *Alzheimer Disease/pc [Prevention & Control] (1256)
99 | *Mild Cognitive Impairment/pc [Prevention & Control] (48)
100 | Cognition Disorders/pc [Preventions & Control] (2341)
101 | or/98–100 (3558)
102 | (91 and 97) or 101 (34439)
103 | exp cohort studies/ (1486668)
104 | cohort$.tw. (295133)
105 | controlled clinical trial.pt. (89967)
106 | epidemiologic studies/ (6963)
107 | (follow up adj stud$).tw. (37939)
108 | longitudinal.tw. (142385)
109 | (observational adj stud$).tw. (48091)
110 | Comparative Study/ (1720170)
111 | 103 or 104 or 105 or 106 or 107 or 108 or 109 or 110 (3175113)
112 | 102 and 111 (7550)
113 | limit 112 to humans (7069)
114 | limit 113 to “all child (0 to 18 years)” (691)
115 | limit 114 to “all adult (19 plus years)” (372)
116 | 113 not 114 (6378)
117 | 115 or 116 (6750)
118 | limit 117 to (addresses or autobiography or bibliography or biography or case reports or clinical conference or comment or congresses or consensus development conference or consensus development conference, nih or dataset or dictionary or directory or editorial or in vitro or interactive tutorial or interview or lectures or legal cases or legislation or letter or news or newspaper article or patient education handout or periodical index or portraits or validation studies or video-audio media or webcasts) (360)
119 | 117 not 118 (6390)
120 | limit 119 to yr=“2009 – 2016” (2812)

## Database: Ovid MEDLINE(R) In-Process & Other Non-Indexed Citations Search Strategy: RCTs

1 | exp Tertiary Prevention/ or exp Secondary Prevention/ or exp Primary Prevention/ (0)
2 | prevent*.ti. (16727)
3 | protect*.ti. (9964)
4 | delay*.ti. (5679)
5 | ((reduc* or decreas* or effect* or lower* or modif* or change* or stop* or improv* or increas* or enhanc* or rais*) and risk*).ti. (5717)
6 | 1 or 2 or 3 or 4 or 5 (37733)
7 | lifestyle*.ti. (1346)
8 | life style.ti. (73)
9 | exp Health Behavior/ (0)
10 | exp Motor Activity/ (0)
11 | ((physical or aerobic* or leisure) and (activit* or fitness)).ti. (3604)
12 | exercis*.ti. (7474)
13 | exp Diet/ (0)
14 | diet*.ti. (11652)
15 | fruit*.ti. (2919)
16 | vegetable*.ti. (892)
17 | nutrition*.ti. (6266)
18 | fat*.ti. (15032)
19 | caffeine.ti. (503)
20 | sodium.ti. (5610)
21 | salt*.ti. (5744)
22 | alcohol*.ti. (9093)
23 | ((smok* or tobacco) and (quit or cessation or stop*)).ti. (976)
24 | ((metacognitive or cognitive or mental or brain or memory or social or perceptual or computer) and (activit* or train* or stimulat* or intervention or engag* or rehab*)).ti. (3677)
25 | exp *Pharmacology, Clinical/ (0)
26 | exp Pharmaceutical Preparations/ (0)
27 | drug*.ti. (21843)
28 | medication*.ti. (3542)
29 | pharmacopsychiatry.ti. (2)
30 | exp Psychopharmacology/ (0)
31 | lovastatin/ or simvastatin/ or pravastatin/ (0)
32 | statin*.ti. (1193)
33 | exp Antihypertensive Agents/ (0)
34 | anti-hypertensive*.ti. (46)
35 | antihypertensive*.ti. (505)
36 | exp Cholinesterase Inhibitors/ (0)
37 | Acetylcholinesterase inhibitor*.ti. (84)
38 | (Donepezil or Aricept or Memantine or Namenda or Rivastigmine or Exelon or Galantamine or razadyne or Quetiapine or seroquel).ti. (565)
39 | cholinesterase inhibitor*.ti. (89)
40 | exp Antibodies, Monoclonal/ or exp Antibodies, Monoclonal, Humanized/ (0)
41 | anti amyloid*.ti. (18)
42 | antiamyloid*.ti. (3)
43 | Solanezumab.ti. (3)
44 | crenezumab.ti. (1)
45 | gantenerumab.ti. (0)
46 | crenezumab.ab. (5)
47 | antiplatlet.ti. (1)
48 | anti-platelet.ti. (74)
49 | (Triflusal or Ticlid or plavix or brilinta or persantine or Ticlopidine or Dipyridomole or Clopidogrel).ti. (515)
50 | exp Hypoglycemic Agents/ (0)
51 | (Pioglitazone or actos or Glucophage or metformin).ti. (1160)
52 | ((gonadal or sex) adj steroid*).ti. (134)
53 | exp Hormone Replacement Therapy/ (0)
54 | estrogen*.ti. (1884)
55 | progest*.ti. (985)
56 | medroxyprogesterone*.ti. (51)
57 | estradiol.ti. (676)
58 | raloxifene.ti. (78)
59 | exp Cyclooxygenase 2 Inhibitors/ (0)
60 | (Celecoxib or Rofecoxib).ti. (207)
61 | exp Anti-Inflammatory Agents, Non-Steroidal/ (0)
62 | (Ibuprofen or Tarenflurbil or flurbiprofen or Flurizan or Naproxen or Aspirin).ti. (1397)
63 | exp Dietary Supplements/ (0)
64 | supplement*.ti. (4634)
65 | nutraceutical*.ti. (127)
66 | exp Nootropic Agents/ (0)
67 | nootropic*.ti. (28)
68 | exp Vitamins/ (0)
69 | exp Minerals/ (0)
70 | omega.ti. (1008)
71 | ginkgo biloba.ti. (149)
72 | ginko biloba.ti. (1)
73 | folate.ti. (495)
74 | fish oil.ti. (242)
75 | saffron.ti. (81)
76 | crocus sativus.ti. (55)
77 | fuzhisan.ti. (1)
78 | melissa.ti. (40)
79 | beta carotene.ti. (163)
80 | vitamin*.ti. (6567)
81 | ((manag* or control* or lower* or reduc* or decreas* or loss or lose) and (weight or BMI or body mass index or overweight or obes* or diabetes or depress* or cardio* or vascular or blood pressure or hypertension or cholesterol or hypercholesterolemia or homocysteine)).ti. (9325)
82 | or/6–81 (152409)
83 | dementia/ or alzheimer disease/ (0)
84 | dement*.ti. (3196)
85 | exp Cognition/ (0)
86 | exp Mild Cognitive Impairment/ or exp Cognition Disorders/ (0)
87 | memory disorders/ (0)
88 | executive funtion/ (0)
89 | exp memory/ (0)
90 | cognition.ti. (1391)
91 | ((cognit* or neurocognit* or memory or neuropsy* or neuro*) adj (impair* or disorder* or dysfunction* or function* ag?ing or declin* or status or perform* or diabil* or disable* or maint* or enhanc*)).ti. (4103)
92 | ((maint* or impair* or disorder* or declin* or enhanc*) adj (cognit* or neurocognit* or memory or neuropsy* or neuro*)).ti. (216)
93 | (amyloid or tau or plasticity).ti. (4251)
94 | ((brain or grey matter or gray matter) adj3 (function* or scan* or mri or volume or chang* or imag*)).ti. (1579)
95 | exp Biological Markers/ (0)
96 | (83 or 86) and 95 (0)
97 | 83 or 84 or 85 or 86 or 87 or 88 or 89 or 90 or 91 or 92 or 93 or 96 (12603)
98 | 82 and 97 (1485)
99 | *Alzheimer Disease/pc [Prevention & Control] (0)
100 | *Mild Cognitive Impairment/pc [Prevention & Control] (0)
101 | Cognition Disorders/pc [Preventions & Control] (0)
102 | or/98–101 (1485)
103 | 98 or 102 (1485)
104 | randomized controlled trials as topic/ (0)
105 | randomized controlled trial/ (759)
106 | random allocation/ (0)
107 | double blind method/ (0)
108 | single blind method/ (0)
109 | clinical trial/ (472)
110 | clinical trial, phase i.pt. (29)
111 | clinical trial, phase ii.pt. (42)
112 | clinical trial, phase iii.pt. (35)
113 | clinical trial, phase iv.pt. (2)
114 | controlled clinical trial.pt. (55)
115 | randomized controlled trial.pt. (759)
116 | multicenter study.pt. (399)
117 | clinical trial.pt. (472)
118 | exp Clinical trials as topic/ (0)
119 | or/104–118 (1245)
120 | (clinical adj trial$).tw. (26676)
121 | ((singl$ or doubl$ or treb$ or tripl$) adj (blind$3 or mask$3)).tw. (9179)
122 | placebos/ (0)
123 | placebo$.tw. (11961)
124 | randomly allocated.tw. (2339)
125 | (allocated adj2 random$).tw. (2515)
126 | 120 or 121 or 122 or 123 or 124 or 125 (40573)
127 | 119 or 126 (41429)
128 | 103 and 127 (147)

## Database: Embase Classic+Embase Search Strategy: RCTs

1 | prevention/ or “prevention and control”/ or primary prevention/ or prophylaxis/ or protection/ (388002)
2 | prevent*.ti. (292863)
3 | protect*.ti. (166106)
4 | delay*.ti. (70519)
5 | ((reduc* or decreas* or effect* or lower* or modif* or change* or stop* or improv* or increas* or enhanc* or rais*) and risk*).ti. (68778)
6 | (biomarker* adj2 enrich*).ti. (29)
7 | intervention*.ti. (128336)
8 | program*.ti. (190084)
9 | multidomain*.ti. (482)
10 | multi-domain*.ti. (196)
11 | multicomponent*.ti. (3473)
12 | multi-component*.ti. (1062)
13 | multifactoral*.ti. (25)
14 | multi-factoral*.ti. (2)
15 | approach*.ti. (256521)
16 | lifestyle*.ti. (13016)
17 | life style.ti. (1723)
18 | exp physical activity/ (295154)
19 | exp exercise/ (263840)
20 | ((physical or aerobic* or leisure) and (activit* or fitness)).ti. (35810)
21 | exercis*.ti. (118665)
22 | exp Diet/ (271531)
23 | diet*.ti. (181510)
24 | fruit*.ti. (23508)
25 | vegetable*.ti. (11437)
26 | nutrition*.ti. (103074)
27 | fat*.ti. (247795)
28 | caffeine.ti. (12266)
29 | sodium.ti. (99989)
30 | salt*.ti. (48776)
31 | alcohol*.ti. (151585)
32 | ((smok* or tobacco) and (quit or cessation or stop*)).ti. (13072)
33 | ((metacognitive or cognitive or mental or brain or memory or social or perceptual or computer) and (activit* or train* or stimulat* or intervention or engag* or rehab*)).ti. (53741)
34 | exp *drug therapy/ (652263)
35 | drug*.ti. (450662)
36 | medication*.ti. (48020)
37 | pharmacopsychiatry.ti. (90)
38 | exp Psychopharmacology/ (27649)
39 | lovastatin/ or simvastatin/ or pravastatin/ (44198)
40 | statin*.ti. (16827)
41 | exp Antihypertensive Agents/ (628950)
42 | anti-hypertensive*.ti. (972)
43 | antihypertensive*.ti. (16198)
44 | exp Cholinesterase Inhibitors/ (83861)
45 | Acetylcholinesterase inhibitor*.ti. (1226)
46 | (Donepezil or Aricept or Memantine or Namenda or Rivastigmine or Exelon or Galantamine or razadyne or Quetiapine or seroquel).ti. (7323)
47 | cholinesterase inhibitor*.ti. (1672)
48 | exp Antibodies, Monoclonal/ or exp Antibodies, Monoclonal, Humanized/ (394269)
49 | anti amyloid*.ti. (214)
50 | antiamyloid*.ti. (40)
51 | Solanezumab.ti. (43)
52 | crenezumab.ti. (2)
53 | gantenerumab.ti. (9)
54 | crenezumab.ab. (14)
55 | antiplatlet.ti. (8)
56 | anti-platelet.ti. (1311)
57 | (Triflusal or Ticlid or plavix or brilinta or persantine or Ticlopidine or Dipyridomole or Clopidogrel).ti. (8156)
58 | exp Hypoglycemic Agents/ (408843)
59 | (Pioglitazone or actos or Glucophage or metformin).ti. (12917)
60 | ((gonadal or sex) adj steroid*).ti. (4750)
61 | exp Hormone Replacement Therapy/ (52856)
62 | estrogen*.ti. (59100)
63 | progest*.ti. (35701)
64 | medroxyprogesterone*.ti. (2555)
65 | estradiol.ti. (22509)
66 | raloxifene.ti. (1622)
67 | exp Cyclooxygenase 2 Inhibitors/ (42579)
68 | (Celecoxib or Rofecoxib).ti. (3619)
69 | exp Anti-Inflammatory Agents, Non-Steroidal/ (490780)
70 | (Ibuprofen or Tarenflurbil or flurbiprofen or Flurizan or Naproxen or Aspirin).ti. (30083)
71 | exp Dietary Supplements/ (72740)
72 | supplement*.ti. (59036)
73 | nutraceutical*.ti. (1163)
74 | exp Nootropic Agents/ (98194)
75 | nootropic*.ti. (693)
76 | exp Vitamins/ (573824)
77 | exp Minerals/ (36345)
78 | omega.ti. (10406)
79 | ginkgo biloba.ti. (2538)
80 | ginko biloba.ti. (20)
81 | folate.ti. (10490)
82 | fish oil.ti. (3894)
83 | saffron.ti. (625)
84 | crocus sativus.ti. (434)
85 | fuzhisan.ti. (12)
86 | melissa.ti. (356)
87 | beta carotene.ti. (3702)
88 | vitamin*.ti. (113036)
89 | ((manag* or control* or lower* or reduc* or decreas* or loss or lose) and (weight or BMI or body mass index or overweight or obes* or diabetes or depress* or cardio* or vascular or blood pressure or hypertension or cholesterol or hypercholesterolemia or homocysteine)).ti. (127982)
90 | or/1–89 (6007082)
91 | *dementia/ or *alzheimer disease/ (122973)
92 | (dementia or cognitive impair*).ti. (60302)
93 | *Cognition/ (57927)
94 | *Mild Cognitive Impairment/ (5955)
95 | *memory disorders/ (2392)
96 | *executive funtion/ (0)
97 | exp *memory/ (86144)
98 | cognition.ti. (12039)
99 | ((cognit* or neurocognit* or memory or neuropsy* or neuro*) adj (impair* or disorder* or dysfunction* or function* ag?ing or declin* or status or perform* or diabil* or disable* or maint* or enhanc*)).ti. (50252)
100 | ((maint* or impair* or disorder* or declin* or enhanc*) adj (cognit* or neurocognit* or memory or neuropsy* or neuro*)).ti. (2750)
101 | (amyloid or tau or plasticity).ti. (59657)
102 | ((brain or grey matter or gray matter) adj3 (function* or scan* or mri or volume or chang* or imag*)).ti. (23708)
103 | exp Biological Markers/ (172233)
104 | (91 or 94) and 103 (4462)
105 | 91 or 92 or 94 or 95 or 96 or 97 or 101 or 104 (274389)
106 | *Alzheimer Disease/pc [Prevention & Control] (2840)
107 | *Mild Cognitive Impairment/pc [Prevention & Control] (42)
108 | 106 or 107 (2870)
109 | 90 and 105 (57490)
110 | 108 or 109 (58108)
111 | limit 110 to human (41595)
112 | limit 111 to (embryo <first trimester> or infant <to one year> or child <unspecified age> or preschool child <1 to 6 years> or school child <7 to 12 years> or adolescent <13 to 17 years>) (1366)
113 | limit 112 to (adult <18 to 64 years> or aged <65+ years>) (596)
114 | (111 not 112) or 113 (40825)
115 | Clinical trial/ (861651)
116 | Randomized controlled trial/ (394622)
117 | Randomization/ (69534)
118 | Single blind procedure/ (21500)
119 | Double blind procedure/ (130682)
120 | Crossover procedure/ (46320)
121 | Placebo/ (286985)
122 | Randomi?ed controlled trial$.tw. (129567)
123 | Rct.tw. (19484)
124 | Random allocation.tw. (1561)
125 | Randomly allocated.tw. (24259)
126 | Allocated randomly.tw. (2119)
127 | (allocated adj2 random).tw. (905)
128 | (waitlist or wait list).tw. (4382)
129 | 115 or 116 or 117 or 118 or 119 or 120 or 121 or 122 or 123 or 124 or 125 or 126 or 127 or 128 (1271460)
130 | Case study/ (45524)
131 | Case report.tw. (324413)
132 | Abstract report/ or letter/ (967648)
133 | 130 or 131 or 132 (1330767)
134 | 129 not 133 (1236125)
135 | 114 and 134 (9013)
136 | limit 135 to (book or book series or conference abstract or conference paper or conference proceeding or “conference review” or editorial or letter or note or short survey or trade journal) (2271)
137 | 135 not 136 (6742)
138 | limit 137 to yr=“2009 -Current” (2443)

## Database: Embase Classic+Embase Search Strategy: Observational Studies

1 | prevention/ or “prevention and control”/ or primary prevention/ or prophylaxis/ or protection/ (388002)
2 | prevent*.ti. (292863)
3 | protect*.ti. (166106)
4 | delay*.ti. (70519)
5 | ((reduc* or decreas* or effect* or lower* or modif* or change* or stop* or improv* or increas* or enhanc* or rais*) and risk*).ti. (68778)
6 | (biomarker* adj2 enrich*).ti. (29)
7 | intervention*.ti. (128336)
8 | program*.ti. (190084)
9 | multidomain*.ti. (482)
10 | multi-domain*.ti. (196)
11 | multicomponent*.ti. (3473)
12 | multi-component*.ti. (1062)
13 | multifactoral*.ti. (25)
14 | multi-factoral*.ti. (2)
15 | approach*.ti. (256521)
16 | lifestyle*.ti. (13016)
17 | life style.ti. (1723)
18 | exp physical activity/ (295154)
19 | exp exercise/ (263840)
20 | ((physical or aerobic* or leisure) and (activit* or fitness)).ti. (35810)
21 | exercis*.ti. (118665)
22 | exp Diet/ (271531)
23 | diet*.ti. (181510)
24 | fruit*.ti. (23508)
25 | vegetable*.ti. (11437)
26 | nutrition*.ti. (103074)
27 | fat*.ti. (247795)
28 | caffeine.ti. (12266)
29 | sodium.ti. (99989)
30 | salt*.ti. (48776)
31 | alcohol*.ti. (151585)
32 | ((smok* or tobacco) and (quit or cessation or stop*)).ti. (13072)
33 | ((metacognitive or cognitive or mental or brain or memory or social or perceptual or computer) and (activit* or train* or stimulat* or intervention or engag* or rehab*)).ti. (53741)
34 | exp *drug therapy/ (652263)
35 | drug*.ti. (450662)
36 | medication*.ti. (48020)
37 | pharmacopsychiatry.ti. (90)
38 | exp Psychopharmacology/ (27649)
39 | lovastatin/ or simvastatin/ or pravastatin/ (44198)
40 | statin*.ti. (16827)
41 | exp Antihypertensive Agents/ (628950)
42 | anti-hypertensive*.ti. (972)
43 | antihypertensive*.ti. (16198)
44 | exp Cholinesterase Inhibitors/ (83861)
45 | Acetylcholinesterase inhibitor*.ti. (1226)
46 | (Donepezil or Aricept or Memantine or Namenda or Rivastigmine or Exelon or Galantamine or razadyne or Quetiapine or seroquel).ti. (7323)
47 | cholinesterase inhibitor*.ti. (1672)
48 | exp Antibodies, Monoclonal/ or exp Antibodies, Monoclonal, Humanized/ (394269)
49 | anti amyloid*.ti. (214)
50 | antiamyloid*.ti. (40)
51 | Solanezumab.ti. (43)
52 | crenezumab.ti. (2)
53 | gantenerumab.ti. (9)
54 | crenezumab.ab. (14)
55 | antiplatlet.ti. (8)
56 | anti-platelet.ti. (1311)
57 | (Triflusal or Ticlid or plavix or brilinta or persantine or Ticlopidine or Dipyridomole or Clopidogrel).ti. (8156)
58 | exp Hypoglycemic Agents/ (408843)
59 | (Pioglitazone or actos or Glucophage or metformin).ti. (12917)
60 | ((gonadal or sex) adj steroid*).ti. (4750)
61 | exp Hormone Replacement Therapy/ (52856)
62 | estrogen*.ti. (59100)
63 | progest*.ti. (35701)
64 | medroxyprogesterone*.ti. (2555)
65 | estradiol.ti. (22509)
66 | raloxifene.ti. (1622)
67 | exp Cyclooxygenase 2 Inhibitors/ (42579)
68 | (Celecoxib or Rofecoxib).ti. (3619)
69 | exp Anti-Inflammatory Agents, Non-Steroidal/ (490780)
70 | (Ibuprofen or Tarenflurbil or flurbiprofen or Flurizan or Naproxen or Aspirin).ti. (30083)
71 | exp Dietary Supplements/ (72740)
72 | supplement*.ti. (59036)
73 | nutraceutical*.ti. (1163)
74 | exp Nootropic Agents/ (98194)
75 | nootropic*.ti. (693)
76 | exp Vitamins/ (573824)
77 | exp Minerals/ (36345)
78 | omega.ti. (10406)
79 | ginkgo biloba.ti. (2538)
80 | ginko biloba.ti. (20)
81 | folate.ti. (10490)
82 | fish oil.ti. (3894)
83 | saffron.ti. (625)
84 | crocus sativus.ti. (434)
85 | fuzhisan.ti. (12)
86 | melissa.ti. (356)
87 | beta carotene.ti. (3702)
88 | vitamin*.ti. (113036)
89 | ((manag* or control* or lower* or reduc* or decreas* or loss or lose) and (weight or BMI or body mass index or overweight or obes* or diabetes or depress* or cardio* or vascular or blood pressure or hypertension or cholesterol or hypercholesterolemia or homocysteine)).ti. (127982)
90 | or/1–89 (6007082)
91 | *dementia/ or *alzheimer disease/ (122973)
92 | (dementia or cognitive impair*).ti. (60302)
93 | *Cognition/ (57927)
94 | *Mild Cognitive Impairment/ (5955)
95 | *memory disorders/ (2392)
96 | *executive funtion/ (0)
97 | exp *memory/ (86144)
98 | cognition.ti. (12039)
99 | ((cognit* or neurocognit* or memory or neuropsy* or neuro*) adj (impair* or disorder* or dysfunction* or function* ag?ing or declin* or status or perform* or diabil* or disable* or maint* or enhanc*)).ti. (50252)
100 | ((maint* or impair* or disorder* or declin* or enhanc*) adj (cognit* or neurocognit* or memory or neuropsy* or neuro*)).ti. (2750)
101 | (amyloid or tau or plasticity).ti. (59657)
102 | ((brain or grey matter or gray matter) adj3 (function* or scan* or mri or volume or chang* or imag*)).ti. (23708)
103 | exp Biological Markers/ (172233)
104 | 91 or 92 or 94 or 99 or 100 (177159)
105 | *Alzheimer Disease/pc [Prevention & Control] (2840)
106 | *Mild Cognitive Impairment/pc [Prevention & Control] (42)
107 | 105 or 106 (2870)
108 | 90 and 104 (46186)
109 | 107 or 108 (46804)
110 | limit 109 to human (37668)
111 | limit 110 to (embryo <first trimester> or infant <to one year> or child <unspecified age> or preschool child <1 to 6 years> or school child <7 to 12 years> or adolescent <13 to 17 years>) (928)
112 | limit 111 to (adult <18 to 64 years> or aged <65+ years>) (353)
113 | (110 not 111) or 112 (37093)
114 | Clinical study/ (132584)
115 | longitudinal study/ (85243)
116 | prospective study/ (322344)
117 | cohort analysis/ (230562)
118 | (cohort adj stud*).mp. (158158)
119 | (observational adj stud*).mp. (119842)
120 | (follow up adj stud*).mp. (57729)
121 | (epidemiologic* adj stud*).mp. (88591)
122 | (cross sectional adj stud*).mp. (205524)
123 | or/114–122 (1136620)
124 | 113 and 123 (4143)
125 | limit 124 to (book or book series or chapter or conference abstract or conference paper or conference proceeding or “conference review” or editorial or erratum or letter or note or “review” or short survey or trade journal) (1652)
126 | 124 not 125 (2491)
127 | limit 126 to yr=“2009 -Current” (1644)

## Database: PsycINFO Search Strategy: RCTs

1 | prophylaxis/ or prevention/ (14810)
2 | prevent*.ti. (21271)
3 | protect*.ti. (8537)
4 | delay*.ti. (5830)
5 | ((reduc* or decreas* or effect* or lower* or modif* or change* or stop* or improv* or increas* or enhanc* or rais*) and risk*).ti. (7006)
6 | intervention*.ti. (36138)
7 | program*.ti. (35798)
8 | multidomain*.ti. (22)
9 | multi-domain*.ti. (34)
10 | multicomponent*.ti. (176)
11 | multi-component*.ti. (101)
12 | lifestyle*.ti. (2645)
13 | ((metacognitive or cognitive or mental or brain or memory or social or perceptual or computer) and (activit* or train* or stimulat* or intervention or engag* or rehab*)).ti. (16817)
14 | 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9 or 10 or 11 or 12 or 13 (126101)
15 | *dementia/ or *alzheimer disease/ (35185)
16 | *mild cognitive impairment/ (0)
17 | ((cognit* or neurocognit* or memory or neuropsy* or neuro*) adj (impair* or disorder* or dysfunction* or function* ag?ing or declin* or status or perform* or diabil* or disable* or maint* or enhanc*)).ti. (15609)
18 | ((maint* or impair* or disorder* or declin* or enhanc*) adj (cognit* or neurocognit* or memory or neuropsy* or neuro*)).ti. (990)
19 | (amyloid or tau or plasticity).ti. (9730)
20 | ((brain or grey matter or gray matter) adj3 (function* or scan* or mri or volume or chang* or imag*)).ti. (4219)
21 | biological marker/ (6893)
22 | dementia/ or alzheimer disease/ (39250)
23 | 21 and 22 (1529)
24 | 15 or 16 or 17 or 18 or 19 or 20 or 23 (58609)
25 | 14 and 24 (4017)
26 | limit 25 to human (3317)
27 | limit 26 to (embryo <first trimester> or infant <to one year> or child <unspecified age> or preschool child <1 to 6 years> or school child <7 to 12 years> or adolescent <13 to 17 years>) [Limit not valid in PsycINFO; records were retained] (72)
28 | limit 27 to (adult <18 to 64 years> or aged <65+ years>) [Limit not valid in PsycINFO; records were retained] (12)
29 | (26 not 27) or 28 (3257)
30 | limit 29 to (clinical trial or randomized controlled trial or controlled clinical trial or multicenter study or phase 1 clinical trial or phase 2 clinical trial or phase 3 clinical trial or phase 4 clinical trial) [Limit not valid in PsycINFO; records were retained] (3257)
31 | limit 30 to (book or book series or conference abstract or conference paper or conference proceeding or “conference review” or editorial or letter or note or “review” or short survey or trade journal) [Limit not valid in PsycINFO; records were retained] (283)
32 | 30 not 31 (2974)
33 | limit 32 to yr=“2009 -Current” (2013)

## Database: PsycINFO Search Strategy: Observational Studies

1 | prophylaxis/ or prevention/ (14810)
2 | prevent*.ti. (21271)
3 | protect*.ti. (8537)
4 | delay*.ti. (5830)
5 | ((reduc* or decreas* or effect* or lower* or modif* or change* or stop* or improv* or increas* or enhanc* or rais*) and risk*).ti. (7006)
6 | intervention*.ti. (36138)
7 | program*.ti. (35798)
8 | multidomain*.ti. (22)
9 | multi-domain*.ti. (34)
10 | multicomponent*.ti. (176)
11 | multi-component*.ti. (101)
12 | lifestyle*.ti. (2645)
13 | ((metacognitive or cognitive or mental or brain or memory or social or perceptual or computer) and (activit* or train* or stimulat* or intervention or engag* or rehab*)).ti. (16817)
14 | 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9 or 10 or 11 or 12 or 13 (126101)
15 | *dementia/ or *alzheimer disease/ (35185)
16 | *mild cognitive impairment/ (0)
17 | ((cognit* or neurocognit* or neuropsy* or neuro*) adj (impair* or disorder* or dysfunction*)).ti. (9474)
18 | 15 or 16 or 17 (41904)
19 | 14 and 18 (2846)
20 | limit 19 to human (2537)
21 | (cohort or longitudinal or prospective).ti,ab. (115078)
22 | exp Longitudinal Studies/ (1595)
23 | Prospective Studies/ (216)
24 | 21 or 22 or 23 (115252)
25 | limit 24 to “reviews (best balance of sensitivity and specificity)” (53066)
26 | 24 not 25 (62186)
27 | 20 and 26 (85)
28 | limit 27 to yr=“2009 -Current” (55)

## Cochrane Central Register of Controlled Trials

Precise search on dementia, cognitive impairment terms

## Database: Ovid MEDLINE(R) Search Strategy

1 | exp Memory Disorders/ or exp Neuropsychological Tests/ or exp Alzheimer Disease/ or exp Cognition/ or exp Cognition Disorders/ (298451)
2 | exp Alzheimer Disease/ (73521)
3 | ((cognit* or memory) adj2 (impair* or declin*)).ti,ab. (58569)
4 | exp Mild Cognitive Impairment/ (3643)
5 | cognition.ti,ab. (34845)
6 | (cognitive adj (performan* or test*)).ti,ab. (15238)
7 | 1 or 2 or 3 or 4 or 5 or 6 (329242)
8 | exp Cardiovascular Diseases/dh, dt, rh, su, th [Diet Therapy, Drug Therapy, Rehabilitation, Surgery, Therapy] (766074)
9 | exp Depression/dh, dt, th [Diet Therapy, Drug Therapy, Therapy] (21954)
10 | exp Sleep Wake Disorders/dh, dt, th [Diet Therapy, Drug Therapy, Therapy] (19655)
11 | (sleep adj (quality or duration or time)).ti. (2355)
12 | exp Diabetes Mellitus, Type 2/dh, dt, th [Diet Therapy, Drug Therapy, Therapy] (32195)
13 | 8 or 9 or 10 or 11 or 12 (837027)
14 | 7 and 13 (8871)
15 | limit 14 to (clinical study or clinical trial, all or clinical trial, phase i or clinical trial, phase ii or clinical trial, phase iii or clinical trial, phase iv or clinical trial or comparative study or controlled clinical trial or meta analysis or multicenter study or observational study or pragmatic clinical trial or randomized controlled trial or systematic reviews) (2669)
16 | limit 15 to yr=“2009 -Current” (1210)