# Abbreviations

3MS: Modified Mini-Mental State Examination
ACE: Angiotensin converting enzyme inhibitors
ACTIVE: Advanced Cognitive Training for Independent and Vital Elderly
AD: Alzheimer’s Disease
ADAS-Cog: Alzheimer’s Disease Assessment Scale-Cognitive Subscale
ADL: Activities of daily living
AE: Adverse Events
APC: Annualized percentage change
ARB: Antiotensin receptor blocker
AVLT: Auditory Verbal Learning Test
BCT: Brief cognitive test
BEM-144: Batterie d’Efficience Mnesique 144
BID: Twice daily
BMI: Body Mass Index
BNT: Boston Naming Test
BVMT: Brief Visuospatial Memory Test
BVRT: Benton Visual Retention Test
C: Control
CAMCOG: Cambridge Cognition Examination
CANTAB PAL: Cambridge Neuropsychological Test Automated Battery Paired Associated Learning Test
CANTAB: Cambridge Neuropsychological Test Automated Battery Paired Associated Learning Test
CATD: Clinical Alzheimer’s-type Dementia
CDR: Clinial Dementia Rating
CEE: Conjugated equine estrogen
CERAD: Consortium to Establish a Registry for Alzheimer’s Disease
CI: Confidence interval
CLOX-1: Clock Drawing Test
CSF: Cerebrospinal fluid
CHD: Coronary heart disease
COWAT: Controlled Oral Word Association Test
CPT: Continuous Performance Task
CT: Computerized tomography
CVFT: Category Verbal Fluency Test
CVLT: California Verbal Learning Test
DHA: Docosahexaenoic acid
DHEA: dehydroepiandrosterone
DMS48: Delayed Matching-to-Sample Task
DS: Digit Span (Forward or Backward)
DSM: Diagnostic Statistical Manual of Mental Disorders
DSST: Digit Symbol Substitution Test
DVT: Digit Vigilance Test
EBMT: East Boston Memory Test
EPA: Eicosapentaenoic acid
ES: Effect size
FAB: Frontal Assessment Battery
FCRST: Free and Cued Selective Reminding Test
FDG-PET: Fluorodeoxyglucose positron emission tomography
fMRI: Functional magnetic resonance imaging
F-TICS: French version, Telephone Interview Cognitive Status
HC: Hippocampus
HKLLT: Hong Kong List Learning Test
HRT: Hormone replacement therapy
HVLT: Hopkins Verbal Learning Test
I: Intervention
IADL: Instrumental activities of daily living
IHAMS: Iowa Health and Active Minds Study
IOM: Institute of Medicine
ITT: Intention to treat
IU: International Units
k: Number of studies included
KQ: Key Question
LDL: Low density lipoprotein
MCI: Mild cognitive impairment
MG: Milligrams
MMSE: Mini-Mental State Examination
MNP: Multidomain neuropsychological test performance
MRI: Magnetic resonance imaging
n: Number of participants
NINCDS-ADRDA: National Institute of Neurological and Communicative Disorders and Stroke-Alzheimer’s Disease and Related Disorders Association
NR: Not reported
NS: Not significant
NSAIDs: Nonsteroidal anti-inflammatory drugs
NTB: Neuropsychological test battery
OR: Odds ratio
PALS: Paired Association Learning Test
PET: Positron emission tomography
PICOTS: Populations, Interventions, Comparisons, Outcomes, Timing, and Setting
PRM: Pattern Recognition Memory
QAD: Every other day
RAVLT: Rey Auditory Verbal Learning Test
RBANS: Repeatable Battery for Neuropsychological Status
RBMT: Rivermead Behavioral Memory Test
RCFT: Rey-Osterrieth Complex Figure Test
RCI: Reliable Change Index
RCPM: Raven’s Colored Progressive Matrices
RCT: Randomized controlled trial
ROB: Risk of bias
RT: Reaction time
SCWT: Stroop Test (color, word, interference)
SDMT: Symbol Digit Modalities Test
SERM: Selective estrogen receptor modulator
SoE: Strength of Evidence
SPECT: Single photon emission computed tomography
SWM: Spatial Working Memory
TIA: Transient ischemic attack
TICS: Telephone Interview for Cognitive Status
TICS-M: Telephone Interview for Cognitive Status-Modified
TMT: Trail Making Test (parts A and/or B)
UFOV: Useful Field of View
VP: Verbal proficiency
VR: Visual Reproduction
VRM: Verbal Recognition Memory
WAIS: Wechsler Adult Intelligence Scale
WMS: Wechsler Memory Scale