# Results for Key Questions (KQs) 2a and 2b

## Results of the Search

We included 129 studies (57 studies from an existing review, 47 newly identified additional studies reported in 48 articles, and 25 studies from ClinicalTrials.gov). Figure 6 summarizes the search and selection of the primary studies. (See Appendix C for list of citations excluded at full-text level, with reasons for exclusion)

Figure 6 Summary of the literature search for primary studies: treating symptoms

^*^ Reviewers did not need to agree on reason for exclusion

KQ = Key Question, RCT = Randomized controlled trial

Figure 6 describes the screening and review process of our literature search review for section KQ2a and KQ2b. 4,945 unique citations were identified. During the title and abstract screening process, 4,751 citations were excluded. In the full-text article screening process, a further 119 citations were excluded.

The breakdown of the included studies for KQ2a and b by study design is:

- KQ2a -106 randomized controlled trials (RCTs) (57 RCTs from existing systematicreview, 24 additional RCTs and 25 from ClinicalTrials.gov);
- KQ2b - Supplements (alpha-lipoic acid, acetyl-L-carnitine)- 7 RCTs;
- KQ2b - Acupuncture - 1 RCT;
- KQ2b - Cognitive behavioral therapy -1 RCT;
- KQ2b - Electrical Stimulation- 7 RCTs;
- KQ2b - Electromagnetic Stimulation- 4 RCTs;
- KQ2b - Spinal Cord Stimulation - 2 RCTs;
- KQ2b - Surgical Decompression - 1 RCT (reported in 2 articles)

The findings are summarized in Tables 12 to 17.

Table 12 Summary of key effectiveness results on pain and quality of life

Outcomes^*^ Comparison | Number of Studies Reporting Outcome (N) | Findings | Strength of Evidence^**^
Pain intensity Placebo-controlled comparisons
Key anticonvulsants
Pregabalin vs placebo | 16 studies Previous SR: 6 RCTs Additional identified studies: 6 RCTs ClinicalTrials.gov: 4 RCTs (N=4017) | The previous review concluded that pregabalin was more effective than placebo for reducing pain (Standardized mean difference, −0.55 [95% Crl −0.94 to −0.15]) For an updated meta-analysis of 15 RCTs, the Standardized mean difference was −0.34 (95% CI, −0.50 to −0.18). The new studies did not change the conclusion. | Low
Gabapentin vs placebo | 5 studies Previous SR: 3 RCTs Additional identified studies: 2 RCTs, one with 2 different arms at maximum dose (N=766) | The previous review concluded that there was no difference in effectiveness of gabapentin compared to placebo for reducing pain (Standardized mean difference −0.73 [95% CrI, −1.54 to 0.09]). Additional identified RCTs at maximum dose were consistent with this finding (Standardized mean difference −0.65 [95% CI, −1.1 to −0.23], −0.27 [95% CI, −0.7 to 0.14]) and −0.20 ([95% CI, −0.46 to 0.06]). The new studies did not change the conclusion. | Low
Oxcarbazepine vs placebo | 3 studies Previous SR: 3 RCTs Additional identified studies: None (N=634) | The previous review concluded that oxcarbazepine was more effective than placebo for reducing pain (Standardized mean difference −0.45 [CrI,−0.68 to −0.21]). We did not identify new studies. | Low
Key serotonin- noradrenaline reuptake inhibitors
Duloxetine vs placebo | 7 studies Previous SR: 5 RCTs Additional identified studies: 2 RCTs (N=2203) | The previous review concluded that duloxetine was more effective than placebo for reducing pain (Standardized mean difference −1.33 [Crl, −1.82 to −0.86]). Additional identified RCTs were consistent with this finding (Standardized mean difference −0.33 [95% CI, −0.54 to −0.12] for the one study where this could be calculated). The new studies did not change the conclusion. | Moderate
Venlafaxine vs placebo | 2 studies Previous SR: 2 RCTs Additional identified studies: None (N=304) | The previous review concluded that venlafaxine was more effective than placebo for reducing pain (Standardized mean difference, −1.53 [Crl, −2.41 to −0.65]) We did not identify new studies. | Moderate
Tricyclic antidepressants
Tricyclic antidepressants (TCAs) vs placebo | 4 studies Previous SR: 4 RCTs Additional identified studies: None (N=81) | The previous review concluded that TCAs were more effective than placebo for reducing pain (Standardized mean difference −0.78 [Crl, −1.24 to −0.33]). We did not identify new studies. | Low
Opioids
Oxycodone vs. placebo | 4 studies Previous SR: 2 RCTs Additional identified studies: 1 RCT ClinicalTrials.gov: 1 RCT (N = 583) | The previous review concluded that opioids (all studies of oxycodone) were not more effective than placebo for reducing pain [Standardized mean difference −0.58 (95% CrI, −1.53 to 0.36)]. For two additional identified RCTs, one published trial reported a standardized mean difference of −0.24 [95% CI, −0.47 to −0.01] and one trial from clinicaltrials.gov found a standardized mean difference of −0.06 (95% CI, −0.46 to 0.34) The new studies did not change the conclusion. | Low
Atypical opioids (tramadol and tapentadol) vs. placebo | 5 studies Previous SR: 2 RCTs Additional identified studies: 3 RCTs (N=1177) | The previous review did not report on atypical opioids separately. We conducted a new meta-analysis. Meta-analysis – Standardized mean difference −0.68 (95% CI, -.80 to −0.56). Atypical opioids are more effective than placebo for reducing pain. | Low
Topical capsaicin
Topical capsaicin 0.075% vs placebo | 5 studies Previous SR: 3 RCTs Additional identified studies: 2 RCTs (N=432) | The previous review concluded that capsaicin 0.075% was more effective than placebo for reducing pain (Standardized mean difference −0.91 [Crl, −1.18 to −0.08]). The pooled Standardized mean difference from a meta-analysis of 3 studies (2 from previous review and 1 new study) where a Standardized mean difference could be calculated was −0.46; 95% CI, −0.95 to 0.03) Capsaicin is not more effective than placebo for reducing pain. | Low
Topical capsaicin patch 8% vs placebo | 1 study Previous SR: None Additional identified studies: None Clinicaltrials.gov: 1 RCT (N=369) | We could not draw conclusions based on insufficient evidence from one study. | Insufficient
Dextromethorphan
Dextromethorphan vs placebo | 3 studies Previous SR: 2 RCTs Additional identified study: 1 RCT (N =416) | The previous review concluded that dextromethorphan was not more effective than placebo for reducing pain (Standardized mean difference −0.28 [95% CrI, −1.49 to 0.92]). We could not calculate a Standardized mean difference for the newly identified study. The new study did not change the conclusion | Low
Mexiletine vs placebo | 5 studies Previous SR: 5 RCTs Additional identified studies: None (N=389) | The previous review concluded that mexiletine was not more effective than placebo for reducing pain (Standardized mean difference, −0.29 [95% CrI, −0.91 to 0.33]). We did not identify new studies. | Low
Botulinum toxin vs placebo | 2 studies Previous SR: None Additional identified studies: 2 RCTs (N=60) | The previous review did not include this drug. Botulinum toxin is more effective than placebo for reducing pain. Standardized mean difference ranged from −0.96 to −0.79 | Low
Key drug-drug comparisons
Duloxetine vs. pregabalin | 2 studies Previous SR: 1 RCT Additional identified study: 1 RCT (N =411) | We could not draw conclusions due to insufficient evidence. | Insufficient
Quality of life^***^ - Griebeler et al did not assess this outcome
Key anticonvulsants
Gabapentin vs placebo | 3 RCTs Additional identified studies: 3 RCTs (N =646) | We could not draw conclusions due to incomplete reporting of results and inconsistent results. | Insufficient
Pregabalin vs placebo | 10 RCTs Additional identified studies: 7 RCTs (N =1746) | We could not draw conclusions due to incomplete reporting of results and inconsistent results. | Insufficient
Key serotonin-noradrenaline reuptake inhibitors
Duloxetine vs placebo | 3 RCTs (N=1006) | We could not draw conclusions due to incomplete reporting of results and inconsistent results. | Insufficient
Opioids
Atypical opioids vs placebo | 4 RCTs (N =1157) | We could not draw conclusions due to incomplete reporting of results and inconsistent results | Insufficient

* Only key comparison and outcomes are included in the table.

** we graded only the key outcomes (pain and quality of life)

Since this is an update of a prior systematic review, for the pain outcome the results are generally reported as (1) results from the Griebeler et al. network meta-analysis, (2) whether results from additional identified studies are consistent or inconsistent with Griebeler et al., and (3) specific results from these additional studies.

Anticonvulsants are not summarized as a drug category overall, given divergent results among drugs. A new meta-analysis was conducted for pregabalin and atypical opioids, given a significant number of new studies with potentially inconsistent results with Griebeler et al.

** Griebeler et al. did not abstract results for quality of life outcome; we abstracted these results from the studies. Since many studies did not report actual values for quality of life, but only statistical significance, results could only be summarized as the number of studies reporting statistical significance.

Please see Appendix table E-4 and E-5 -Strength of evidence table for domains

RCT= randomized clinical trial; SR= systematic review; SMD= standardized mean difference; CrI=credible interval; SNRIs = Serotonin–norepinephrine reuptake inhibitors

Table 13 Number of studies addressing pain symptoms of diabetic peripheral neuropathy

Drug class | N of studies included from Griebeler et al. | N of studies in updated search | N of completed studies identified in ClinicalTrials.gov only (N of studies with reported results)
Placebo comparisons
Anticonvulsants
Carbamazepine | 1 | 0 | 0
Gabapentin | 3 | 2 | 1(0)
Lacosamide | 4 | 0 | 1(0)
Lamotrigine | 3 | 0 | 0
Oxcarbazepine | 3 | 0 | 0
Pregabalin | 6 | 6 | 10(4)
Topiramate | 2 | 1 | 1(0)
Valproic acid | 2 | 0 | 0
Zonisamide | 0 | 1 | 0
Serotonin-Noradrenaline Reuptake Inhibitors (SNRIs)
Desvenlafaxine | 0 | 1 | 0
Duloxetine | 5 | 2 | 0
Milnacipran | 0 | 0 | 1(0)
Venlafaxine | 2 | 0 | 0
Tricyclic antidepressants (TCAs)
Amitriptyline | 1 | 0 | 0
Desipramine | 1 | 0 | 0
Imipramine | 2 | 0 | 0
Opiates
Oxycodone | 2 | 1 | 1(1)
Tapentadol ER | 1 | 2 | 0
Tramadol/Acetaminophen | 1 | 1 | 0
Topical Agents
Capsaicin 0.075% | 3 | 2 | 1(0)
Capsaicin 8% patch | 0 | 0 | 2(1)
Clonidine | 0 | 1 | 1(0)
Lidocaine | 0 | 0 | 2 (0)
N-methyl-D-aspartate receptor antagonists
Dextromethorphan | 2 | 1 | 0
Class IB antiarrhythmic
Mexiletine | 5 | 0 | 0
Botulinum Toxin | 0 | 2 | 1 (0)
Cannabinoids
Nabilone | 0 | 1 | 1 (0)
Nabiximols | 0 | 0 | 1 (1)
Trials Comparing Medications of Different Classes
Amitriptyline vs. Duloxetine vs. Pregabalin | 1 | 0 | 0
Amitriptyline vs. Lamotrigine | 1 | 0 | 0
Amitriptyline vs. Maprotiline vs. Placebo | 1 | 0 | 0
Amitriptyline vs. Topical Capsaicin 0.075% | 1 | 0 | 0
Duloxetine vs. Pregabalin^*^ | 0 | 1 | 2 (0)
Gabapentin vs. Amitriptyline | 1 | 0 | 0
Gabapentin vs. Topical lidocaine | 0 | 0 | 1 (0)
Pregabalin vs. Amitriptyline | 1 | 0 | 0
Imipramine vs. Paroxetine | 1 | 0 | 0
Venlafaxine vs. Carbamazepine | 1 | 0 | 0

* 1 study listed above compared these two drugs in a three-armed trial

TCAs -Tricyclic antidepressants, SNRIs-Serotonin-Noradrenaline Reuptake Inhibitors

Table 14 Number of studies reporting quality of life as an outcome

Number of studies reporting quality of life | Number of studies with statistically significant results favoring treatment over placebo | Number of studies with non-statistically significant results
Anticonvulsants vs. placebo
Pregabalin (10 studies) | 4^121, 124–126^ | 6 ^97, 127, 128^; 3(NCT01474772, NCT01455415; NCT00785577)
Gabapentin (3 studies) | 1^129^ | 2^97, 130^
Oxcarbazepine (3 studies) | 1^131^ | 2 ^132, 133^
Topiramate (1 study) | 0 | 1^134^
Lacosamide (1 study) | 1^135^ | 0
Serotonin-noradrenaline reuptake inhibitors vs. placebo
Duloxetine (3 studies) | 1 ^136^ | 2^104, 137, 138^
Desvenlafaxine (1 study) | 0 | 1^105^
Typical opioids vs. placebo
Typical opioids (1 study) | 0 | 1^139^
Atypical opioids vs. placebo
Tramadol (2 studies) | 1 ^109^ | 1 ^140^
Tapentadol (2 studies) | 2^108,141^ | 0
Topical drugs vs. placebo
Capsaicin 8% patch (1 study) | 0 | 1 (NCT01533428)
Other drugs vs. placebo
Dextromethorphan (1 study) | 1^142^ | 0
Botulinum toxin (1 study) | 0 | 1^115^
Nabilone (1 study) | 1^114^ | 0
Nabiximols (1 study) | 0 | 1 (NCT00710424)
Drug vs. drug comparisons study
Anticonvulsant vs. Serotonin–norepinephrine reuptake inhibitors vs. tricyclic antidepressant (1 study) | 1^143^ | 0

Studies that did not report statistics are not shown in the table

Table 15 Summary of findings of harms reported in pharmacological studies

Adverse effects | Intervention | Comparison (Placebo -/Drug)
Anticonvulsants
anorexia | 10.9 – 20% | 0 – 0.9%
back pain | 9 –11% | 2.8 –6%
Cardiovascular | 25% | 8.3%
dermatological | 8 – 33.3% | 9 – 25%
diarrhea | 10.7 –12.3% | 3.7% to 8.6%
dizziness | 2.5% to 52.5% | 0% to 18%
Fatigue | 4–16% | 2–11%
headache | 4.4% to 36.6% | 3.7% to 38
nausea | 2.4% to 41 | 0% 16%
paresthesia | 12 –20% | 5 –9%
Peripheral edema | 8 – 17% | 0 – 31.8%
respiratory | 33.3%, | 25%
restlessness/insomnia | 25% | 0%
somnolence | 3% to 40% | 0 – 16.7%
taste perversion | 14% | 0%
urinary | 25% | 0%
weight change | 25% | 8.3%
weight gain | 14.6% | 1.2%
weight loss | 14% | 6%
Serotonin-noradrenaline reuptake inhibitors (SNRIs)
Constipation | 7% to 19% | 2% to 8%
Dizziness | 1.6% to 26.1% | 6% to 11%
Dry mouth | 3.2% to 13% | 2.2%
Dyspepsia | 9% to 10% | 1%
Nausea | 10% to 32% | 2% to 12%
Somnolence | 8% to 28% | 1% to 8%
Vomiting | 2.9% to 10.1% | 2.2%
Tricyclic antidepressants (TCAs)
Dizziness | 8 –16% | 3%
Insomnia | 35% | 15%
Somnolence | 4% to 69% | 12 – 40%
Xerostomia | 26% to 89% | 8% to 45%
Topical capsaicin
Burning pain at the application site | 13.98 – 63% | 2.7% to 19%
Opioids- oxycodone
Constipation | 45 – 59% | 14 – 17%
Fatigue | 18% | 8%
Nausea | 36 – 73% | 8 – 36%
Somnolence | 40 – 41% | 1 – 47%
Atypical opioids
Constipation | 6 –22% | 1–5%
Dizziness | 6.3 – 7.2% | 1.3 – 2%
Headache | 2.4 –5% | 5–5.3%
Nausea | 11.9 to 23% | 3–9.9%
Somnolence | 6 –12% | 0.7 –6%
Vomiting | 12.7% | 4.6%

Table 16 Dropouts due to adverse effects reported in all the studies

Drug Class | Intervention | Dropouts Due to Adverse Effects (%)
Anticonvulsants | Carbamazepine | 3
Anticonvulsants | Gabapentin | 8 – 21
Anticonvulsants | Lacosamide | 8.3 – 42.3
Anticonvulsants | Lamotrigine | 7.4 – 21.1
Anticonvulsants | Oxcarbazepine | 10.8 – 40.9
Anticonvulsants | Pregabalin | 2.5 – 25.6
Anticonvulsants | Topiramate | 12 – 30.4
Anticonvulsants | Valproic Acid | 3.4 – 4.8
Anticonvulsants | Zonisamide | 38.5
Serotonin-noradrenaline reuptake inhibitors (SNRIs) | Desvenlafaxine | 8 – 30.4
Serotonin-noradrenaline reuptake inhibitors (SNRIs) | Duloxetine | 4.3 – 19.3
Serotonin-noradrenaline reuptake inhibitors (SNRIs) | Venlafaxine | 6 – 9.8
Tricyclic antidepressants (TCAs) | Amitriptyline | 3.6 – 38.6
Tricyclic antidepressants (TCAs) | Desipramine | 10 – 13
Tricyclic antidepressants (TCAs) | Imipramine | Not reported
Opiates and Atypical Opiates | Oxycodone | 3 – 70
Opiates and Atypical Opiates | Tapentadol | 8.1 – 16.3
Opiates and Atypical Opiates | Tramadol | 8.1 – 13.8
Topical Agents | Capsaicin | 0 – 8.6
Topical Agents | Clonidine | 3
N-methyl-D-aspartate Receptor Antagonists | Dextromethorphan | 20.2–25.2
Class IB Antiarrhythmics | Mexiletine | 13.3
Botulinum Toxin | Botulinum Toxin | 0
Cannabinoids | Nabilone | Not reported

Table 17 Summary of key findings of nonpharmacologic interventions for symptoms and quality of life

Outcomes | Comparison | Number of studies reporting outcome (N) | Findings | Strength of Evidence^*^
Pain | Supplements: Alpha-lipoic acid vs placebo | 5 RCTs (N =984) | Alpha-lipoic acid is more effective than placebo for reducing pain in short-term studies Standardized mean difference for pain ranged from −2.64 to −0.54 for the two studies where this could be calculated | Low
Pain | Electrical stimulation: Transcutaneous electrical nerve stimulation vs sham | 4 RCTs (N =118) | Transcutaneous electrical nerve stimulation is not more effective than sham therapy for reducing pain in short-term studies. Standardized mean difference ranged from −5.4 to −0.19 for the three studies where this could be calculated | Low
Pain | Electromagnetic stimulation: Frequency-modulated electromagnetic neural stimulation vs sham | 2 RCTs (N =132) | Frequency-modulated electromagnetic neural stimulation is more effective than sham for reducing pain short-term, but not long-term. Standardized mean difference ranged from −2.62 to −1.31 for short-term (<12 week) outcomes. | Low
Pain | Spinal cord stimulation vs usual care | 2 RCTs (N =96) | Spinal cord stimulation is more effective than usual care for reducing pain. Standardized mean difference ranged from −1.83 to −1.57. | Low
Quality of life | Spinal cord stimulation vs usual care | 2 RCTs (N =96) | We could not draw conclusions due to incomplete reporting of results. | Insufficient

RCT = Randomized Controlled Trial

* we graded only the key outcomes (pain and quality of life)

Please see Appendix table E-6-Strength of evidence table for domains

## KQ2a Benefits and Harms of Pharmacologic Treatment Options To Improve Symptoms

### Key Points

- The anticonvulsants pregabalin and oxcarbazepine (low strength of evidence), the serotonin-noradrenaline reuptake inhibitors duloxetine and venlafaxine (moderate strength of evidence), the drug classes of tricyclic antidepressants (low strength of evidence) and atypical opioids (tramadol and tapentadol) (low strength of evidence), and the intradermal neurotoxin botulinum toxin (low strength of evidence) were more effective than placebo for reducing pain in diabetic peripheral neuropathy.
- We were unable to draw conclusions for quality of life with pharmacologic treatments due to incomplete reporting across studies (insufficient strength of evidence).
- All oral treatments had substantial rates of adverse effects, with dropout rates due to adverse effects of greater than 9 percent for all effective treatments.

### Description of Included Studies for Treatment of Pain

#### Summary of Studies Included in Systematic Review

Griebeler et al. conducted a systematic review, identifying RCTs through April 2014, to evaluate the comparative effectiveness of oral and topical analgesics for the outcome of pain for painful diabetic peripheral neuropathy. The investigators included 65 RCTs (57 RCTs eligible for our review) that included 10,639 patients and compared 21 medications. Included trials were mostly short-term (less than three months) (mean followup: 14 weeks for all short- and long-term studies); very few extended beyond 3 months, and these studies of longer duration (which were all less than 5 months in length) were not included in their main analyses. The review authors evaluated the efficacy of one outcome, pain, by standardizing the results from pain intensity scales to estimated standard mean difference. The review authors included studies reporting less than 3 months of followup in a network meta-analysis to compare drug classes and individual drugs to placebo and to each other. Key findings from their network meta-analysis of short-term studies are shown in Appendix D. The review authors concluded that the evidence is scant and often derived from trials of less than five months in duration, the majority of which had an unclear or high risk of bias.

#### Summary of Studies Identified From Updated Search and ClinicalTrials.gov

Our literature search identified twenty-five comparisons (24 RCTs) not included in the Griebeler et al. review. (One RCT^97^ included two drugs (pregabalin and gabapentin in separate arms, both compared to placebo.) Followup ranged from three to 18 weeks (we included all additional studies in the update and did not separate out studies by length of followup), with a median of 12 weeks of duration. Seventeen trials were multicenter studies. Four trials had academic funding and two did not report a funding source; the remaining twenty-one were industry funded. All of the trials were published between 1987 and 2015. The number of participants ranged from 20 to 804. All trials were placebo-controlled except for one trial comparing duloxetine, pregabalin, and combination therapy, (only the duloxetine and pregabalin comparison was abstractable and reported here.)^98^

We found an additional 25 trials in ClinicalTrials.gov for which we were unable to identify a publication. Of these, 18 trials are completed, two are withdrawn, three are recruiting, and two have an unknown status. For the 18 completed studies without publications, five (28%) were completed during or prior to 2008, three (17%) were completed in 2010, four (22%) were completed in 2013, three (17%) were completed in 2014, and three (17%) were completed in 2015. Less than half (39%) reported results in ClinicalTrials.gov (Table 13).

### Outcomes

#### Pain

##### Placebo-Controlled Comparisons

###### Anticonvulsants

Forty-two RCTs assessed the effect of anticonvulsants compared with placebo on pain (20 RCTs from the Griebeler et al. review, 10 RCTs from an updated search, and 13 RCTs from ClinicalTrials.gov). We analyzed each anticonvulsant separately, given heterogeneity in effectiveness.

###### Pregabalin Versus Placebo

Twenty-two RCTs (6 RCTs from the Griebeler et al. review, 6 RCTs from an updated search, and 10 RCTs from ClinicalTrials.gov, 4 of which had available data) assessed the effect of pregabalin compared with placebo on pain.

We conducted a new meta-analysis for pregabalin, given the additional studies with inconsistent findings. (A meta-analysis limited to the five RCTs published since Griebeler et al. where a standardized mean difference could be calculated, and all four unpublished RCTs, did not show that pregabalin was more effective than placebo for reducing pain (Standardized mean difference, −0.13; 95% CI, −0.27 to 0.01) (data not shown). In addition, we identified six RCTs in ClinicalTrials.gov with no available results.

In the overall pooled results from the full meta-analysis, based on the 15 (out of 16) trials where a standardized mean difference could be calculated from Griebeler et al., the updated search, and RCTs from ClinicalTrials.gov with available data, pregabalin is more effective than placebo for reducing pain (Standardized mean difference, −0.34; 95% CI, −0.50 to −0.18). (Figure 7). (Standardized mean difference could not be calculated due to incomplete crossover trial data for one additional study,^99^ but this study reported statistically insignificant findings.) However, we found no trials longer than 3 months, this is a small effect size, and there was significant heterogeneity in the findings (I-squared, 80%) (Figure 7). We considered the strength of evidence low due to inconsistency across the studies, as well as because of suspected reporting bias.

Figure 7 Standardized mean difference in pain scores comparing pregabalin with placebo stratified by studies found in the published literature versus those found only in ClinicalTrials.gov

CI = confidence interval; CT.gov = ClinicalTrials.gov; ES = effect size; NPS = Numeric Pain Scale; NRS = Numeric Rating Scale; VAS = Visual Analog Scale

Figure 7 describes the meta-analyses of the calculated standardized mean difference in pain scores for studies comparing placebo vs placebo. This includes studies from previous review, studies from additional searches and ClinicalTrials.gov.

###### Gabapentin Versus Placebo

Six RCTs (3 RCTs from the Griebeler et al. review, 2 RCTs from an updated search, and 1 RCT from ClinicalTrials.gov) assessed the effect of gabapentin compared with placebo on pain.

Griebeler et al. (based on three short-term RCTs) concluded that gabapentin was not more effective than placebo (Standardized mean difference, −0.73 [95% CrI, −1.54 to 0.09]). Two RCTs from the updated search were consistent with this finding, with an Standardized mean difference of −0.65 [95% CI, −1.1 to −0.23], −0.27 [95% CI, −0.7 to 0.14] and −0.20 [95% CI, −0.46 to 0.06]) (including results from two different doses for gabapentin in one study).^97, 100^ All the trials were of gabapentin encarbil (which is a long-acting bioequivalent) and short-term in duration. One RCT (NCT00904202) from ClinicalTrials.gov was completed in June 2003 but did not report any results. Since results of new studies were consistent with Griebeler et al., we did not conduct a new meta-analysis.

Overall, based on the available data, gabapentin is no more effective than placebo for reducing pain. We considered the strength of evidence low due to inconsistency across the studies, suspected reporting bias, and unclear risk of bias.

###### Oxcarbazepine Versus Placebo

Three RCTs from the Griebeler et al. review assessed the effect of oxcarbazepine compared with placebo on pain.

Griebeler et al. concluded (based on three 16 week studies), that oxcarbazepine was more effective than placebo (Standardized mean difference from long-term network, −0.45 [95% CrI, −0.68 to −0.21]) (small effect size). Oxcarbazepine is more effective than placebo for reducing pain. We considered the strength of evidence low due to inconsistency among the studies, incomplete reporting and unclear risk of bias.

###### Topiramate Versus Placebo

Four RCTs (2 RCTs from the Griebeler et al. review, 1 RCT from the updated search, and 1 RCT from ClinicalTrials.gov) assessed the effect of topiramate compared with placebo on pain.

Griebeler et al. concluded (based on one RCT) that topiramate was not more effective than placebo (Standardized mean difference was −0.45 [95% CrI, −1.98 to 1.08]) in short-term studies. In long-term studies, Griebeler et al. also concluded that topiramate was not more effective than placebo for reducing pain based on one RCT. One additional identified RCT of topiramate was consistent with this finding, with a standardized mean difference of −0.14 (95% CI, −0.62 to 0.34).^101^ One RCT (NCT00231673) from ClinicalTrials.gov was completed in January 2003 but did not report any results.

Overall, based on the available data, topiramate is no more effective than placebo. We considered the strength of evidence low due to consistency across the studies, imprecise findings and unclear risk of bias.

###### Zonisamide Versus Placebo

We identified one RCT of zonisamide with an standardized mean difference of −0.63 (95% CI, −1.47 to 0.21).^102^ Griebeler et al. did not include zonisamide. We were unable to draw a conclusion about zonisamide. We considered the strength of evidence as insufficient given only one study.

###### Other Anticonvulsants (Valproic Acid, Lacosamide, Carbamazepine, Lamotrigine) Versus Placebo

Griebeler et al. found that all other anticonvulsants evaluated (valproic acid, lacosamide, carbamazepine, lamotrigine) were not more effective than placebo in short-term studies (see Appendix D for details), and we identified no additional RCTs. We considered the strength of evidence low for all of these anticonvulsants, due to inconsistency across the studies, except for carbamazepine, where we could not draw conclusions due to insufficient evidence from one study.

###### Antidepressants

###### Serotonin-Noradrenaline Reuptake Inhibitors Versus Placebo

Ten studies assessed the effect of serotonin-noradrenaline reuptake inhibitor antidepressants compared with placebo on pain [7 RCTs from the Griebeler et al. review (all short-term RCTs) and 3 RCTs from an updated search (2 for duloxetine^103, 104^ and 1 for desvenlafaxine^105^)].

Greibeler at al. concluded that serotonin-noradrenaline reuptake inhibitor antidepressants overall were more effective for the outcome of pain compared with placebo [Standardized mean difference, −1.36 (95% CrI, −1.77 to −0.95)] (large effect size). In additional identified studies, standardized mean difference ranged from −0.33 to −0.11 for serotonin-noradrenaline reuptake inhibitors [−0.33 (95% CI, −0.54 to −0.12) and −0.11 (95% CI, −0.42 to 0.21)].

We did not redo the Griebeler et al. meta-analysis for the outcome of pain for serotonin-noradrenaline reuptake inhibitors because the evidence both overall for this drug class and for duloxetine specifically was consistent with the results of Griebeler et al. and the conclusions are therefore not changed.

###### Individual Serotonin-Noradrenaline Reuptake Inhibitors

Duloxetine Versus Placebo. Seven studies (5 RCTs from the Griebeler et al. review and 2 RCTs from an updated search) assessed the effect of duloxetine compared with placebo on pain.

Griebeler et al. (based on 5 RCTs) concluded that duloxetine was more effective than placebo (Standardized mean difference, −1.33 [95% Crl, −1.82 to −0.86]) (large effect size). Findings from two RCTs from an updated search were consistent with this finding. Standardized mean difference was −0.33 [95% CI, −0.54 to −0.12]) although standardized mean difference could be calculated only for one study.^103^. For other RCT of duloxetine, ^104^ standardized mean difference could not be calculated, but the least squares mean change from baseline was −2.8 in the duloxetine arm and −2.1 in the placebo arm (p=0.03 in the direction favoring effectiveness of duloxetine). Since results of additional identified studies were consistent with Griebeler et al., we did not conduct a new meta-analysis.

Overall, based on the available data, duloxetine is more effective than placebo. We considered the strength of evidence moderate due to consistency across the studies, precise findings and unclear risk of bias.

Venlafaxine Versus Placebo. Two RCTs (2 RCTs from Griebeler et al. and 0 RCT from updated search) assessed the effect of venlafaxine compared with placebo on pain.

Griebeler et al. concluded (based on two RCTs) that venlafaxine was more effective than placebo (Standardized mean difference, −1.53 [95% Crl, −2.41 to −0.65]) (large effect size). We considered the strength of evidence moderate due to consistency across the studies, precise findings and unclear risk of bias.

Desvenlafaxine Versus Placebo. One RCT (Griebeler et al. did not include desvenlafaxine) identified from the updated search assessed the effect of desvenlafaxine compared with placebo on pain.

Standardized mean difference was −0.11 (95% CI, −0.42 to 0.21).^105^ We could not draw conclusions due to insufficient evidence from one study.

Milnacipran Versus Placebo. One RCT (NCT01288937) identified in ClinicalTrials.gov completed in October 2014 did not report any results.

###### Tricyclic Antidepressants

Four RCTs from the Griebeler et al. review reported in five articles assessed the effect of tricyclic antidepressants compared with placebo on pain. All four RCTs were short-term. We identified no new studies.

Griebeler et al. concluded that tricyclic antidepressants were more effective than placebo in reducing pain (Standardized mean difference, −0.78 [95% Crl, −1.24 to −0.33]) and that one specific drug, amitriptyline, was more effective than placebo (Standardized mean difference, −0.72 [95% Crl, −1.35 to −0.08]) (moderate effect size).

We considered the strength of evidence low for the effectiveness of tricyclic antidepressants overall in reducing pain due to imprecision and inconsistency across the studies, low for the individual drug imipramine due to imprecision, inconsistency across the studies, and high risk of bias, and insufficient for desipramine and amitriptyline.

###### Analgesics

###### Opioids (Oxycodone) Versus Placebo

Four RCTs (2 RCTs from the Griebeler et al. review described in three articles, one RCT from an updated search, and one RCT from ClinicalTrials.gov) assessed the effect of opioids (all on oxycodone controlled-release) compared with placebo on pain.

Griebeler et al. concluded, based on network meta-analysis of the three articles, that oxycodone was not more effective than placebo [Standardized mean difference, −0.58 (95% CrI, −1.53 to 0.36)]. The individual standardized mean differences for the 2 RCTs were −0.50 (95% CI, −0.81 to −0.18) and −1.28 (−1.92 to −0.64). The additional identified published trial ^106^ found a Standardized mean difference, −0.24 (95% CI, −0.47 to −0.01). One RCT (NCT00944697) from ClinicalTrials.gov reported pain results but the results were limited to the final values. The standardized mean difference was −0.06 (95% CI, −0.46 to 0.34). We did not pool these studies due to high statistical heterogeneity (I-squared = 79% and 75% for the published studies and the overall results, respectively).

Overall, based on the available data, opioids are not more effective than placebo for reducing pain. We considered the strength of evidence low due to inconsistency across the studies, suspected reporting bias, and unclear risk of bias.

###### Atypical Opioids (Tapentadol, Tramadol) Versus Placebo

Five RCTs assessed the effect of atypical opioids compared with placebo on pain, two from Griebeler et al. (one each with tramadol/acetaminophen and tapentadol extended-release) and three additional identified studies (two with tapentadol^107, 108^ and one with tramadol^109^).

Griebeler et al. did not report on atypical opioids separately. Given different mechanisms of action and the number of new studies, we reanalyzed these separately from other opioids and conducted a new meta-analysis in this drug class. Standardized mean difference ranged from −7.0 to −0.36 (from −1.43 to −0.46 for tapentadol and from −7.0 to −0.36 for tramadol). Excluding the outlier,^109^ the standardized mean difference for the meta-analysis of all five studies was −0.57 (95% CI, −0.69 to −0.44), and including the outlier, was −0.68 (95% CI, −0.80 to −0.56) (Figure 8) (moderate effect size).

Figure 8 Meta-analysis of calculated standardized mean differences for studies comparing an atypical opioid with placebo for pain outcome

CI=confidence interval; N=sample size; SMD=standardized mean difference

Figure 8 describes the meta-analyses of the calculated standardized mean difference in pain scores for studies comparing an atypical opioid vs placebo. This includes studies from previous review and studies from additional searches.

Overall, based on the available data, atypical opioids are more effective than placebo for reducing pain.We considered the strength of evidence low for atypical opioids overall due to precise but inconsistent findings across the studies, as well as concerns about study methodology. There were particular concerns for the tapentadol studies as they were inconsistent with standards for pain trials, including using nonstandard primary pain outcomes and withdrawal study methodology (of concern for studies of opioids, where withdrawal causes additional symptoms). For individual drugs, we considered the strength of evidence low for use of tapentadol to reduce pain due to these issues, and low for tramadol due to inconsistency across the studies and unclear risk of bias.

###### Topical Agents

###### Capsaicin Versus Placebo

We summarized results separately for the 0.075% capsaicin cream and 8% capsaicin topical patch, given different use and potential heterogeneity in effectiveness. Eight RCTs (3 RCTs from Griebeler et al. review and 2 from an updated search, all of 0.075% capsaicin, and 3 from ClinicalTrials.gov (1 of 0.075% and 2 of the 8% patch, only the trial on the 8% patch had results available) assessed the effect of capsaicin compared with placebo on pain.

For 0.075% capsaicin, three RCTs from Griebeler et al. and two RCTs from an updated search^110, 111^ assessed topical capsaicin for pain. Griebeler et al. concluded that capsaicin was more effective than placebo (Standardized mean difference, −0.91 [95% Crl, −1.18 to −0.08]). For the one additional RCT identified where standardized mean difference could be calculated, standardized mean difference was −0.04 (95% CI: −0.65 to 0.72). ^110^ The other RCT ^111^ only reported the percentage of patients with more than 20 percent improvement for pain severity, which was 71 percent in the capsaicin group compared to 46 percent in the placebo group and was not statistically significant. The results from these two studies were not consistent with the results of Griebeler et al. In a pooled meta-analysis of the three studies where a SMD could be calculated (including 1 new study), topical capsaicin 0.075% was ineffective (SMD, −0.46; 95% CI, −0.95 to 0.03) (Figure 9). Overall, based on the available data, capsaicin 0.075% is no more effective than placebo for reducing pain. We considered the strength of evidence low for capsaicin in reducing pain, due to inconsistency across the studies, imprecision and unclear risk of bias.

Figure 9 Meta-analysis of calculated standardized mean differences for studies comparing topical capsaicin 0.075 percent with placebo for pain outcome

CI=confidence interval; SMD=standardized mean difference, VAS =visual analogue scale

Figure 9 describes the meta-analysis of calculated standardized mean differences for studies comparing topical capsaicin 0.075% with placebo for pain outcome. This includes studies from previous review and studies from additional searches.

For the 8% patch, one trial (NCT01533428) from ClinicalTrials.gov found that the mean between-group difference in the average daily pain score was (in the direction favoring capsaicin) −7.1% (95% CI, −12.9% to −1.2%). We were unable to draw a conclusion on the capsaicin 8% patch, given insufficient evidence from one study.

###### Clonidine Versus Placebo

Two RCTs (1 from an updated search and 1 from ClinicalTrials.gov) assessed the effect of the topical version of the alpha-agonist clonidine compared with placebo on pain (this drug was not included in Griebeler et al. review). For the RCT from an updated search, standardized mean difference was −0.50 (95% CI, −1.0 to 0.004). ^112^ One RCT (NCT02068027) from ClinicalTrials.gov was completed in 2015 but did not report the results. We considered the strength of evidence insufficient for clonidine based on insufficient evidence from one study.

###### Lidocaine Versus Placebo

We did not identify any studies of topical lidocaine that met inclusion criteria. Two RCTs from ClinicalTrials.gov that addressed this treatment did not report the results (NCT02363803 and NCT00904202). One of the trial (NCT02363803) is currently recruiting and is not expected to complete until 2018.

###### Other Agents

###### Dextromethorphan Versus Placebo

Three RCTs (2 from Griebeler et al. review and 1 from an updated search) assessed the effect of dextromethorphan compared with placebo on pain.

Griebeler et al. concluded that dextromethorphan was not more effective than placebo (Standardized mean difference, −0.28 [95% CrI, −1.49 to 0.92]). For the RCT identified from an updated search ^113^, standardized mean difference could not be calculated, but the mean difference in pain scores between baseline and followup was −2.6 in the dextromethorphan and −2.0 in the placebo group (in the direction favoring effectiveness of dextromethorphan, p<0.0001). These results were inconsistent with the findings of Griebeler et al. However, we could not update the meta-analysis for dextromethorphan versus placebo for pain because the study reported insufficient data for pooling.

Overall, based on the findings of Griebler et al., dextromethorphan is not more effective than placebo for reducing pain. We considered the strength of evidence low for dextromethorphan due to imprecision and inconsistency of results.

###### Cannabinoids (Nabilone and Nabiximols) Versus Placebo

Three RCTs (1 from an updated search and 2 from ClinicalTrials.gov, 1 of which had available data) assessed the effect of different cannabinoids (nabilone and nabiximols) compared with placebo on pain. The Griebeler et al. review did not include this drug class.

For one RCT of the synthetic cannabinoid nabilone, the standardized mean difference for pain was −1.02 (95% CI, −1.82 to −0.21). ^114^ We could not draw conclusions for nabilone due to insufficient evidence from one study.

One RCT (NCT00710424) from ClinicalTrials.gov reported results for pain for the oromucosal spray cannabinoid extract nabiximols. The standardized mean difference for pain was 0.02 (95% CI, −0.21 to 0.26).

We could not draw conclusions for nabiximols due to insufficient evidence from one study.

###### Botulinum Toxin Versus Placebo

Three RCTs (2 RCTs from an updated search and 1 RCT from ClinicalTrials.gov) assessed the effect of botulinum toxin compared with placebo on pain. Griebeler et al. did not include this drug.

The standardized mean difference for pain for botulinum toxin ranged from −0.96 ^115^ to −0.79 ^116^ (moderate to large effect size). One RCT from ClinicalTrials.gov did not report the results. This trial is currently recruiting, and is scheduled to be completed in September 2016.

We considered the strength of evidence as low for botulinum toxin in reducing pain due to imprecise but consistent findings across the studies.

###### Mexiletine Versus Placebo

We did not identify additional studies for the Class IB antiarrhythmic mexiletine. Griebeler et al. concluded (based on 5 RCTs) that mexiletine was not more effective than placebo in reducing pain (Standardized mean difference, −0.29 [95% CrI, −0.91 to 0.33]). Strength of evidence for this conclusion was low, given imprecision, inconsistency across the studies, and unclear risk of bias.

###### Ketamine Versus Placebo

We did not identify any eligible studies of the N-methyl-D-aspartate receptor antagonist ketamine.

##### Drug-Drug Comparisons

Three RCTs reported pain as an outcome in comparing two different anticonvulsants to two different serotonin-noradrenaline reuptake inhibitors [2 RCTs from the Griebeler et al. review (1 of carbamazepine vs. venlafaxine and 1 of pregabalin vs. duloxetine) and one newly identified RCT of pregabalin and duloxetine]. Given differences in effectiveness, we analyzed anticonvulsants separately. The additional identified study included a comparison phase of pregabalin compared with duloxetine, which was consistent with the findings from Griebeler et al. (Standardized mean difference could not be calculated given insufficient data, but 40.9 percent of those treated with duloxetine had more than 30 percent improvement in pain compared to 28.8 percent for pregabalin, p<0.001).^98^

Given the lack of complete data in one of the studies, we considered the strength of evidence insufficient for pregabalin compared to duloxetine in reducing pain, and insufficient for carbamazepine compared to venlafaxine.

Griebeler et al. found no other drug-drug or drug class-drug class comparisons that were significantly different based on more than one study (see Appendix D for details). We considered the strength of evidence insufficient for all other individual drug-drug comparisons.

#### Composite Neuropathic Symptoms Score

The Griebeler et al. review did not address composite neuropathic symptom scores. Three RCTs, all studies that were included in Griebeler et al., evaluated composite scores [2 addressing tricyclic antidepressants, both with imipramine,^117, 118^ with a 6-item scale including pain, paresthesia, and numbness, and 1 with mexilitine^119^ with a 4-item scale including pain and paresthesia.

For tricyclic antidepressants, neither study reported sufficient data for mean differences between intervention and control arms to be calculated; one study reported a statistically significant difference (p<0.01) and one study reported a statistically insignificant difference (p<0.10). For mexilitine, the mean difference between the study arms in the change between baseline and followup scores was zero (exactly the same in both arms).

#### Numbness

The Griebeler et al. systematic review did not address numbness. Three RCTs, all studies that were included in Griebeler et al., evaluated numbness as an outcome^120–122^, all assessing anticonvulsants. Of the three studies, two used a 10-point visual analog scale and reported a mean difference in the change between baseline and followup scores between arms ranging from −1.47 to 0.12 (negative value is in the direction favoring the intervention arm). One study (of pregabalin) reported the percentage of patients rating themselves as improved from baseline to followup, with a difference between arms ranging from 10–15%, depending on the dose (statistically significant at p<0.01 for the 300 mg dose but not the 600 mg dose; 95% CI could not be calculated given the data reported.)

#### Paresthesia

The Griebeler et al. systematic review did not address paresthesia. Three studies [2 from the Griebeler et al. review (1 addressing mexilitine^123^ and 1 of the anticonvulsant pregabalin)^121^ and 1 additional identified study on the atypical opioid tapentadol ER^108^] reported paresthesia as an outcome.

The study of mexilitine reported a mean difference from baseline to followup between the intervention and control arms of −0.9 on a 0–3 scale, with the direction of effect favoring the intervention group (p<0.03).

The anticonvulsant study reported the percentage of patients rating themselves as improved, with a difference between arms ranging from ten to twenty percent, depending on the dose (statistically significant at p<0.01 for the 600 mg dose but not the 300 mg dose; 95% CI could not be calculated given the data reported).

The additional identified withdrawal RCT of tapentadol used the paresthesia/dysesthesia subscale of the Neuropathic Pain Symptom Inventory (NPSI)^108^ and found a mean difference from baseline to followup between the intervention and control arms of −1.3 between groups (95% CI, −1.42 to −1.20), with the direction of effect favoring the intervention group.

#### Quality of Life

The Griebeler et al. systematic review did not assess quality of life. Many studies did not report values for quality of life scores, instead only describing whether the results were statistically significantly different between the study arms. The results are summarized in table 13.

We abstracted the most relevant quality of life subscale using the following hierarchy for the highest therapeutic dose in each RCT: SF-36 physical function, then VAS quality of life score, then EQ-5D overall, then other quality of life score, then SF-36 bodily pain. Comparisons not reported in the table had no studies reporting quality of life. Given that many studies did not report values, but only whether or not results were statistically significant, we could not quantitatively report or synthesize the results.

We considered the strength of evidence insufficient for all classes (serotonin-noradrenaline reuptake inhibitors and atypical opioids) and individual drugs that reported more than one study, due to incomplete reporting of results, inconsistent results, and unclear risk of bias (with suspected reporting bias) (Table 14).

#### Harms

The harms results are summarized in Table 15. For drugs not reported in the table, the Griebeler et al. review did not summarize harms for the drug and we did not identify additional identified studies reporting harms in >10%. Types of harms reported in greater than 10% of participants varied by drug class. Studies of serotonin-norepinephrine reuptake inhibitors and anticonvulsants most commonly reported dizziness, nausea and somnolence while studies of tricyclic antidepressants reported xerostomia, somnolence and insomnia. For both opioids and atypical opioids, the most common adverse effects were constipation, nausea and somnolence. Dropout rates due to adverse effects varied widely from 2.5% up to 70% for oral agents. For non-oral agents, dropouts were less frequent, ranging from 0% to 8.6%.

Griebeler et al. did not summarize dropouts due to adverse effects. We abstracted the data from the studies included in that review as well as from newly identified published studies. The dropout results are summarized in Table 16.

## KQ2b Benefits and Harms of Nonpharmacologic Treatment Options (Alpha-Lipoic Acid, Acetyl-L-Carnitine, Acupuncture, Physical Therapy and Exercise, Cognitive Behavioral Therapy, Electrical Stimulation, Surgical Decompression) To Improve Symptoms

### Key Points

- Alpha-lipoic acid was more effective than placebo for reducing pain, although studies were short-term (<3 months) (low strength of evidence).
- Spinal cord stimulation was more effective than usual care for the outcome of pain (low strength of evidence), but the procedure has risks of severe complications.
- Transcutaneous electrical nerve stimulation (TENS) was not more effective than sham for reducing pain (low strength of evidence).
- Frequency-modulated electromagnetic stimulation was more effective than sham for reducing pain short-term, but not long-term (low strength of evidence).
- We could not draw conclusions for quality of life (insufficient strength of evidence).
- Adverse effects were not systematically assessed in studies.

### Supplements (Alpha-Lipoic Acid, Acetyl-L-Carnitine)

#### Description of Included Studies

Seven RCTs addressed the benefits and/or harms of supplements. Six RCTs evaluated alpha-lipoic acid (ALA) ^144–149^ and one assessed acetyl-l-carnitine.^150^

Doses of alpha-lipoic acid considered to be therapeutic ranged from 600 mg to 1800 mg daily. The dose of acetyl-l-carnitine was 2000 mg/day. Followup ranged from three weeks to four years, with four of the studies five weeks or less in duration. Five studies were multicenter studies. Five studies took place in Europe. All trials were funded by industry. All alpha-lipoic acid studies had the same investigator as the first or last author. Trials were published from 1995 to 2011. The number of participants in the included studies ranged from four to 503 (with a total 1,614 participants for alpha-lipoic acid and 333 participants for acetyl-l-carnitine). All trials were placebo-controlled.

The overall risk of bias for trials was unclear due to poor reporting regarding allocation concealment, random sequence generation, assessing blinding by the outcome, incomplete outcome data, and selective outcome reporting.

#### Outcomes

We did not conduct meta-analyses for any of the outcomes for supplements owing to heterogeneity in study design and length, drug dosing, and outcome measurement and reporting.

#### Pain

Five RCTs reported pain as an outcome (other studies reported only a composite score that included pain),^145, 147–150^ four of which studied alpha-lipoic acid with a study duration of 3 to 5 weeks (the long-term study of alpha-lipoic acid did not report pain separately). Three out of four RCTs of alpha-lipoid acid reported the total symptom score (TSS) subscale for lancinating pain. Standardized mean difference between the intervention group and the control group of the difference from baseline to followup on the total symptom score pain subscale ranged from −2.64 to −0.54, with the direction of effect favoring the intervention group for the two studies in which this could be calculated (Figure 10).

Figure 10 Calculated standardized mean difference between alpha-lipoic acid (ALA) and placebo on change in the total symptom score (TSS) pain subscale

ALA=alpha lipoic acid; CI=confidence interval; Mg/d=milligram per day; SMD=standardized mean difference

Figure 10 describes the forest plot of calculated standardized mean difference for pain continuous outcomes (between baseline and follow-up on the TSS pain subscale) between alpha-lipoic acid and control.

One study reported categorical outcomes only and therefore is not shown in Figure 9. In that study, the percentage of participants with a greater than 30 percent reduction in pain ranged from 70.8 percent to 82.5 percent in the study groups receiving alpha-lipoic acid, compared with 57.6 percent in the placebo group (p<0.05 for only one study group).^147^

One study of alpha-lipoic acid reported the Neuropathy Symptom Change Score – Lower Legs (NSC[LL]) pain severity score, with a mean change in baseline of −7.3 in the treatment group compared with −4.6 in the placebo group (p<0.0001) (neither the standardized mean difference nor 95% CI could be calculated, as standard deviation was not reported).

Alpha-lipoic acid was effective for reducing pain compared to placebo in short-term studies (moderate to large effect size). We considered the strength of evidence low for alpha-lipoic acid in reducing pain, due to inconsistency across the studies and unclear risk of bias, including suspected reporting bias. In particular, only four of the six studies reported pain separately; studies were five weeks or less (the only long-term study did not report pain separately); and standardized mean difference could only be calculated for half the studies where pain outcomes were reported given incomplete data. In addition, we were unable to find any published psychometric evaluation of the total symptom score tool used in most of these studies.

The RCT of acetyl-L-carnitine had a standardized mean difference between the intervention and the control group of the difference from baseline to followup of −3.6, in the direction favoring the intervention group (95% CI, −3.99 to −3.29).^150^

We could not draw conclusions for acetyl-L-carnitine due to insufficient evidence from one study.

#### Composite Outcome

All six RCTs of alpha-lipoic acid reported the Total Symptom Score (TSS) composite scale. The total symptom score is a summary score of the presence, severity and duration of lancinating pain, burning pain, prickling (paresthesia), and numbness, with a range of possible scores from 0 to 14.64.^146^ Some of the studies also reported the individual subscales (described separately in the pain, paresthesia, and numbness sections). Calculated standardized mean differences between the intervention group and the control group of the difference from baseline to followup on the total total symptom score ranged from −2.21 (95% CI, −2.67 to −1.75) to 0.00 (95% CI, −0.19 to 0.19) (for the only long-term study), with the direction of effect favoring the intervention group in the five studies in which the standardized mean difference could be calculated (Figure 9).

One study reported only the median change from baseline, so standardized mean difference could not be calculated (−3.7 in the alpha-lipoic acid group compared with −3 in the placebo group, p=0.447).^146^

Figure 11 Calculated standardized mean difference between alpha-lipoic acid (ALA) and placebo on change in the total symptom score composite scale

ALA=alpha lipoic acid; CI=confidence interval; Mg/d=milligram per day; SMD=standardized mean difference

Figure 11 describes the calculated standardized mean difference between the alpha-lipoic acid intervention group and the control group of the difference from baseline to follow-up on the total TSS composite scale.

#### Numbness

Four RCTs reported numbness as an outcome, all of which used alpha-lipoic acid and had a study duration of 3 to 5 weeks.^145, 147–149^ Three trials reported the Total Symptom Score (TSS) numbness subscale. Standardized mean differences between the intervention group and the control group of the difference from baseline to followup on the total symptom score numbness subscale could be calculated for three studies. These ranged from −0.38 (95% CI, −0.73 to −0.03), with the direction of effect favoring the intervention group, to 0.17 (95% CI, −0.59 to 0.25) (Figure 12).^145, 147, 149^

Figure 12 Calculated standardized mean difference for numbness between alpha-lipoic acid (ALA) and placebo on change in the total symptom score (TSS) numbness subscale

ALA=alpha lipoic acid; CI=confidence interval; Mg/d=milligram per day; SMD=standardized mean difference

Figure 12 describes the calculated standardized mean difference between the alpha-lipoic acid intervention group and the control group of the difference from baseline to follow-up on the TSS numbness subscale.

One trial reported the Neuropathic Symptom Change Score – Lower Legs (NSC[LL]) negative sensation severity subscale (mean change from baseline of −1.2 in alpha-lipoic acid group compared with −0.7 in the placebo group, p=0.043) (neither the standardized mean difference nor 95% CI was calculated as standard deviation was not reported).^148^

#### Paresthesia

Four RCTs reported paresthesia as an outcome, all of which used alpha-lipoic acid and had a study duration of 3 to 5 weeks.^145, 147–149^ Three trials reported the total symptom score (TSS) paresthesia subscale. Standardized mean difference between the intervention group and the control group of the difference from baseline to followup on the total symptom score numbness subscale could be calculated for three studies, ranging from −0.47 (95% CI, −0.81 to −0.12) to −0.04 (95% CI, −0.46 to 0.37), with the direction of effect favoring the intervention group (Figure 13). One RCT reported the NSC[LL] positive sensation severity subscale (neither standardized mean difference nor 95% CI was calculated as standard deviation was not reported) (mean change from baseline of −8.3 in alpha-lipoic acid group compared with −5.0 in the placebo group, p<0.001). ^148^

Figure 13 Calculated standardized mean difference between alpha-lipoic acid (ALA) and placebo on change in the total symptom score (TSS) paresthesia score

ALA=alpha lipoic acid; CI=confidence interval; Mg/d=milligram per day; SMD=standardized mean difference

Figure 13 describes the calculated standardized mean difference between the alpha-lipoic acid intervention group and the control group of the difference from baseline to follow-up on the TSS paresthesia subscale.

#### Harms

Three RCTs, all of which used alpha-lipoic acid, reported adverse effects^145–147^. Rates of specific adverse effects occurring in more than 10 percent of patients in at least one study arm receiving alpha-lipoic acid included nausea, ranging from 1 to 25 percent; vomiting, ranging from 0 to 26 percent; and vertigo, ranging from 4 to 11 percent of participants. Rates were dose-dependent, with the highest rates in the 1800 mg group.^145^

All studies reported dropouts due to adverse effects, ranging from zero percent for 600 mg^145^ to 13 percent for 1800 mg^145^ in study arms. The dropout rate due to adverse effects for acetyl-L-carnitine was 6.3 percent.

### Acupuncture

#### Description of Included Studies

Only one RCT with a sham arm assessed the benefits and/or harms of acupuncture to improve the symptoms of diabetic peripheral neuropathy.^151^ Five acupuncture points on the lower limb of each leg were used in the study in weekly sessions: Liver 3 Taichong, Spleen 6 Sanyinjiao, Spleen 10 Xuehai, Stomach 36 Zusanli and Kidney 3 Taixi. This was a single center study conducted in Europe with government funding. The trial included 45 patients. The study followup was 10 weeks. Overall risk of bias was low.

#### Outcomes

##### Pain

The trial reported pain as an outcome using a visual analog scale. The calculated standardized mean difference between the intervention arm and the control arm of the difference from baseline to followup on numerical pain scales was −0.43 (95% CI, −1.02 to 0.16) in the direction favoring the intervention arm. We could not draw conclusions due to insufficient evidence from one study.

##### Quality of Life

The trial reported quality of life using the Short Form (SF-36) physical component [difference in the mean difference from baseline between the intervention arm and the control arm of −2.2 (95% CI, −5.2, 0.77), in the direction favoring the intervention arm]. We could not draw conclusions due to insufficient evidence from one study.

##### Harms

There were no adverse effects occurring in more than ten percent of patients. The trial reported three dropouts (one from the sham group and two from the intervention group) owing to adverse events.

### Cognitive Behavioral Therapy

#### Description of Included Studies

Only one RCT of 20 patients assessed the benefits and/or harms of cognitive behavioral therapy to improve the symptoms of diabetic peripheral neuropathy.^152^ The intervention included eleven sessions of weekly cognitive behavioral therapy, with a chronic pain management treatment protocol using a therapist manual and corresponding patient workbook and homework. The study followup was four months. This was a single center study conducted in North America using government funding. Overall risk of bias was unclear.

#### Outcomes

##### Pain

Pain was the only outcome reported in this study.^152^ The study used the West Haven Yale Multidimensional Pain Inventory (WHYMPI) pain severity subscale to assess pain severity. Calculated standardized mean difference between the cognitive behavioral therapy arm and the usual care arm of the difference from baseline to followup was −0.87 in the direction favoring the intervention group (p<0.05 with hierarchical linear modeling for longitudinal data). We could not draw conclusions due to insufficient evidence from one study.

##### Harms

The study did not report adverse effects or dropouts due to adverse effects.

### Electrical Stimulation

#### Description of Included Studies

Seven RCTs addressed the benefits and/or harms of electrical stimulation. Four trials evaluated transcutaneous electrical nerve stimulation (TENS), during which electrodes are applied to the skin in affected areas^153–156^ [of these, three used 5–70 milliamperes (mA) and one used microcurrent (30–40 microamperes)]^153^. One trial used percutaneous electrical nerve stimulation (PENS), during which needles are used to deliver the electrical stimulation to affected areas (25 mA).^157^ One trial used stockings with electrodes (50 microamperes)^158^ and one trial used mesodiencephalic modulation, or transcranial stimulation (4–10 mA).^159^ Followup ranged from 3 to 12 weeks, with a median of 8 weeks.

Four of the seven RCTs were parallel trials and three were crossover trials. All were either single center or not reported (presumably single center). Four studies took place in Europe and the remainder in North America. Three had reported industry funding. The number of participants in the included studies ranged from 19 to 100 (with a total of 118 for transcutaneous electrical nerve stimulation (TENS), 50 for percutaneous electrical nerve stimulation (PENS), 30 for stocking electrodes, and 22 for mesodiencephalic). All included a sham arm as the control. The overall risk of bias was unclear for four trials and low for three trials. There was generally unclear bias due to poor reporting regarding the allocation concealment, random sequence generation, assessing blinding by the outcome, and other sources of bias including incomplete outcome data and selective outcome reporting.

#### Outcomes

##### Pain

All seven RCTs of all types of electrical stimulation reported pain as an outcome. Six out of the seven RCTs reported a numerical pain or visual analog scale, while one study (of micro-transcutaneous electrical nerve stimulation) used the Neuropathic Pain Score.^153^ Among the four studies of transcutaneous electrical nerve stimulation specifically, standardized mean differences between the intervention group and the control group on numerical pain scales ranged from −5.4 to −0.19, in the direction favoring the intervention group, in the three studies that used a numerical pain scale (Figure 13). For the study of microTENS that reported the Neuropathic Pain Score, the mean difference in the change from baseline between the groups was 3.73, in the direction favoring the sham arm (not statistically significant). We did not perform a meta-analysis for transcutaneous electrical nerve stimulation owing to study heterogeneity in intervention (micro-TENS versus Transcutaneous electrical nerve stimulation and modes of delivery of the electrical stimulation), outcome measures, and design (different types of run-in periods, including one with amitriptyline).

Standardized mean differences for the other trials were as follows: percutaneous electrical nerve stimulation (PENS), −2.5 (95% CI, −3.0 to −1.9), in the direction favoring the intervention arm; stockings with electrodes, 0.11 (95% CI, −0.63 to 0.85), in the direction favoring the sham arm; and mesodiencephalic stimulation, −0.11 (95% CI, −0.60 to 0.38), in the direction favoring the intervention arm (Figure 14).

Figure 14 Calculated standardized mean difference for reducing pain between electrical stimulation and sham group on numeric pain scale

CI=confidence interval; MDM=mesodiencephalic modulation; N=sample size; PENS=percutaneous electric nerve stimulation; SMD=standardized mean difference; TENS=transcutaneous electric nerve stimulation.

Note that for one study of micro-TENS, standardized mean difference could not be calculated but results were not statistically significant

Figure 14 describes the forest plot of calculated standardized mean differences for studies comparing sham group vs electrical stimulation intervention on numeric pain scale.

Transcutaneous electrical nerve stimulation is not more effective than placebo for reducing pain, and studies were all short-term. We considered the strength of evidence as low for transcutaneous electrical nerve stimulation due to inconsistency across studies and unclear risk of bias. We could not draw conclusions for other methods of electrical stimulation due to insufficient evidence from one study each.

##### Composite Neuropathic Symptoms Score

One RCT of mesodiencephalic modulation reported a composite neuropathic symptoms outcome: the Total Symptom Score (TSS)^159^. Standardized mean difference between the intervention arm and the control arm was −0.28, in the direction favoring the intervention arm (95% CI, −0.77 to 0.21).

##### Numbness

One RCT of transcutaneous electrical nerve stimulation ^154^ reported on the outcome of numbness on the New Total Symptom Score (NTSS-6). Standardized mean difference between the intervention arm and the control arm was 0.05 (95% CI, −0.88 to 0.98), in the direction not favoring the intervention arm.

##### Paresthesia

One RCT of transcutaneous electrical nerve reported on the outcome of paresthesia on the NTSS-6. Standardized mean difference between the intervention arm and the control arm was −0.21 (95% CI, −1.14 to 0.72), in the direction favoring the intervention arm.

##### Quality of Life

Two RCTs reported on the outcome of quality of life using the Short Form (SF-36) physical component. One study of mesodiencephalic stimulation^159^ reported a mean difference in the change from baseline between arms of 4.5, in the direction favoring the intervention arm (SDs were not reported, so 95% CIs could not be calculated) (p<0.01). One study of percutaneous electrical nerve stimulation (PENS) reported a mean difference in the change from baseline between arms of 4.2, in the direction favoring of the intervention arm (95% CI, 3.82 to 4.98).^157^

We did not perform meta-analysis as there were only two studies and these assessed different interventions. We considered the strength of evidence as insufficient for either of these methods of electrical stimulation because of insufficient evidence from one study.

##### Harms

No studies reported adverse effects or dropouts due to adverse effects.

### Electromagnetic Stimulation

#### Description of Included Studies

Four RCTs addressed the benefits and/or harms of electromagnetic stimulation. Two trials evaluated frequency-modulated electromagnetic neural stimulation,^160, 161^ one trial evaluated pulsed electromagnetic fields,^162^ and one trial evaluated repetitive transcranial magnetic stimulation ^163^. Followup ranged from three to 51 weeks (two of the studies were 9 weeks or less). Studies were published between 2005 and 2013. Two of the studies were parallel trials and two were crossover trials. One study was single center and three were multicenter. Three studies took place in Europe and one in North America. Two studies had reported industry funding. The number of participants ranged from 23 to 225 (with totals of 132 participants for frequency-modulated electromagnetic neural stimulation, 225 participants for pulsed electromagnetic fields, and 23 for repetitive transcranial magnetic stimulation). All included a sham arm as the control. The overall risk of bias for trials was low. There was generally low to unclear bias, due to poor reporting regarding the allocation concealment, random sequence generation, and selective outcome reporting. These trials generally had a low risk of bias regarding incomplete outcome data, assessing blinding by the outcome and other sources of bias.

#### Outcomes

##### Pain

All four RCTs reported pain as an outcome on a visual analog scale. For frequency-modulated electromagnetic stimulation, the standardized mean difference between the intervention arm and the control arm for the difference between baseline and followup for the shorter-term outcomes reported in the studies (<12 week outcomes, if reported) ranged from −2.62 to −1.31, in the direction favoring the intervention arm. Bosi et al.^160^ also reported longer-term outcomes, and the difference at the 51-week followup was no longer statistically significant.

For the study of pulsed electromagnetic fields,^162^ the standardized mean difference between the intervention arm and the control arm for the difference between baseline and followup was −0.09 in the direction favoring the intervention group (95% CI, −0.37 to 0.19) (Figure 15).

Figure 15 Calculated standardized mean difference for pain outcome between electromagnetic stimulation and sham group of the difference from baseline to followup

CI=confidence interval; FREMS=frequency modulated electromagnetic neural stimulation; N=sample size; SMD=standardized mean difference

Figure 15 describes the forest plot of calculated standardized mean differences for studies comparing sham versus electromagnetic stimulation intervention for continuous pain outcome (difference from baseline to followup).

The study of repetitive transcranial magnetic stimulation ^163^ did not report standard deviation for the followup and, therefore, standardized mean difference could not be calculated; the time by group effect at the end of the first study period was statistically significant in the direction favoring the intervention group (mean difference between the intervention group and the sham group difference from baseline to followup on a presumed 0–100 VAS of −16.41, p=0.005).

We did not perform meta-analysis given only two studies with the same intervention (frequency-modulated electromagnetic neural stimulation).

Frequency-modulated electromagnetic stimulation is not effective for reducing pain (effective in short term but not in long-term studies). We considered the strength of evidence low due to inconsistency across the studies and unclear risk of bias; in particular, Bosi et al. ^160^ reported immediate relief of pain after each treatment session, but this was not sustained longer-term. We could not draw conclusions for the other methods of electromagnetic stimulation due to insufficient evidence from one study each.

##### Quality of Life

Only one study reported on the outcome of quality of life as a result of frequency-modulated electromagnetic neural stimulation and using the SF-36 total score.^161^ The mean difference between followup and baseline between the intervention arm and the control arm was 0.4, in the direction favoring the intervention arm (not statistically significant). We could not draw conclusions due to insufficient evidence from one study.

##### Harms

No studies reported on adverse effects. Three studies reported dropouts due to adverse effects, two reported no dropouts^160, 161^, and one reported dropouts due to adverse effects of 2.2 percent in the intervention arm and 1.9 percent in the sham arm.

### Spinal Cord Stimulation

#### Description of Included Studies

Two RCTs addressed the benefits and harms of spinal cord stimulation (implanted lead that electrically stimulates the spinal cord dorsal columns).^164, 165^ Followup was 6 months in both studies. Both studies were parallel trials, multicenter, took place in Europe, and were funded by industry. The studies were conducted between 2008 and 2013. The number of participants in the included studies ranged from 36–60 (with a total of 96 participants in both studies). Both studies included a trial phase to determine whether patients responded and used best conventional practice as the control arm. The overall risk of bias was unclear for one trial and low for another trial, with issues of poor reporting regarding the allocation concealment, random sequence generation, and assessing blinding by the outcome.

#### Outcomes

##### Pain

Both RCTs reported pain as an outcome; one used a visual analog scale^164^ and the other the modified Brief Pain Inventory Pain Severity Index.^165^ Standardized mean differences between the intervention arm and the control arm on numerical pain scales ranged from −1.83 to −1.57 (large effect size), in the direction favoring the intervention arm. We did not perform meta-analysis because there were only two studies. Spinal cord compression was effective for reducing pain compared to usual care. We considered the strength of evidence low due to consistency across the studies, imprecision, and low risk of bias. Other concerns included the use of a run-in period to identify responders before implantation and the lack of a sham arm due to the need to implant the device.

##### Quality of Life

Two RCTs reported this outcome, one using the McGill Pain Questionnaire Quality of Life scale [difference in the mean difference from baseline between the intervention arm and the control arm of 7 (95% CI, 5.08 to 8.92)]^164^ and one using the Short Form (SF-36) physical component [difference in the mean difference from baseline between the intervention arm and the control arm of 5.6 (not statistically significant), both in the direction favoring the intervention arm].^165^ We did not perform meta-analysis, as there were only two studies. We were unable to draw a conclusion given incomplete reporting of data. We considered the strength of evidence as insufficient given incomplete data.

##### Harms

There were no adverse effects occurring in >10% of patients. One study reported no dropouts due to adverse effects, one study reported one death (4.5%) and one dropout owing to severe infection (4.5%).

### Surgical Decompression

#### Description of Included Studies

One RCT, randomized by leg and described in two articles, addressed the benefits of surgical decompression (a decompression procedure of the lower extremity nerves according to Dellon in one limb: the common peroneal, deep peroneal, or superficial peroneal nerve).^166, 167^ This trial was a parallel trial, in a single center in Europe, with nonprofit funding. The study was conducted between 2010 and 2013 with 42 patients. Followup was 1 year. Overall risk of bias was unclear, due to poor reporting of methods.

#### Outcomes

##### Pain

The RCT reported pain on a visual analog scale (specifics not reported). The standardized mean difference between the intervention arm and the control arm could not be calculated as standardized difference was not reported; the difference in the mean difference from baseline between the intervention arm and the control arm was −1.8 (p<0.001), in the direction favoring the intervention arm. We could not draw conclusions due to insufficient evidence from one study.

##### Quality of Life

Quality of life scores were the same in both study arms, as people served as their own controls (randomization was by leg).

##### Harms

Neither adverse effects nor dropouts due to adverse effects were reported.

## Discussion

### Key Findings and Implications

We identified a substantial literature on the effectiveness of both pharmacologic (106 studies) and non-pharmacologic (23 studies) approaches to improve the symptoms of diabetic peripheral neuropathy, mostly focusing on the outcome of pain.

The following drug classes were more effective than placebo in reducing pain: serotonin-noradrenaline reuptake inhibitors (moderate strength of evidence), tricyclic antidepressants (low strength of evidence), and atypical opioids (low strength of evidence). Opioids were not more effective for the outcome of pain (low strength of evidence).

For specific drugs within larger classes, we found the following effects for the outcome of pain: for anticonvulsants, only pregabalin and oxcarbazepine were more effective than placebo (low strength of evidence) (although in newer studies and unpublished trials, pregabalin was not more effective than placebo, and oxcarbazepine studies were inconsistent); and for serotonin-noradrenaline reuptake inhibitors, only duloxetine and venlafaxine (moderate strength of evidence). Of note, while most effect sizes were moderate (Cohen’s d >0.5) or large (>0.8),^168^ the effect sizes for pregabalin and oxcarbazepine were small (<0.5). Gabapentin was not effective for the outcome of pain, consistent with the findings of the previous systematic review and consistent with two newly identified studies. The anticonvulsants topiramate or lacosamide were also not more effective in reducing pain compared to placebo. Botulinum toxin was effective for the outcome of pain (low strength of evidence). Dextromethorphan, mexilitine and topical capsaicin 0.075% were not effective, and most other individual drugs had insufficient evidence to draw conclusions. We were unable to draw conclusions for any drug-drug comparisons due to insufficient evidence.

Since values for quality of life were often not reported (only whether results were statistically significant), we were limited to counting the number of statistically significant studies for the most relevant quality of life measures; no drug classes had more than half of studies showing statistically significant results (insufficient strength of evidence). Few studies evaluated paresthesia or numbness, so we could not draw conclusions.

For non-pharmacologic treatments, we found the following effects: for supplements, alpha-lipoic acid (with a moderate effect size) was more effective than placebo for the outcome of pain (low strength of evidence with incomplete reporting of outcomes). For other interventions with more than one study, spinal cord stimulation (although there were not sham arms and there is a risk of serious complications) was more effective than usual care, with a large effect size, and frequency-modulated electrical stimulation was more effective than sham in short-term but not long-term followup; transcutaneous electrical nerve stimulation was not more effective than sham for the outcome of pain (low strength of evidence for all). Supplements were not more effective than placebo for the outcomes of paresthesia or numbness. Quality of life was rarely reported in studies of non-pharmacologic treatments, and where it was reported, for spinal cord stimulation, results were inconsistent and we could not draw a conclusion (low strength of evidence).

Harms reported in greater than 10% of participants varied by drug class. Studies of serotonin-noradrenaline reuptake inhibitors and anticonvulsants reported dizziness, nausea and somnolence most frequently while studies of tricyclic antidepressants reported xerostomia, somnolence and insomnia. For both opioids and atypical opioids, adverse effects were most frequently constipation, nausea and somnolence. It should be noted that comparison data for these studies not only includes placebo but “active controls” to mimic some of the known side effects of medications and thus preserve blinding. Dropout rates due to adverse effects varied widely from 2.5% up to 70% for oral agents. For non-oral agents, dropouts were less frequent, ranging from 0% to 8.6%.

We found no studies for exercise or physical therapy for the outcomes of pain, paresthesia or numbness, nor studies comparing different treatments or combining treatments, and, for quality of life, evidence was either insufficient or there were no studies for all nonpharmacologic treatments. Most trials included were of relatively short duration (<3 months, with many <1 month). In this limited timeframe, investigators are unlikely to capture progression of neuropathic symptoms or long-term dropout rates or side effects.

### Findings in Relationship to What Is Already Known

For pharmacotherapy, we updated the network meta-analysis by Griebeler et al.^169^ which searched through April 2014, and we identified 24 additional published studies and 25 unpublished studies from ClinicalTrials.gov. The Griebeler et al. review addressed only the outcome of pain and concluded that serotonin-noradrenaline reuptake inhibitors (specifically venlafaxine and duloxetine), tricyclic antidepressants (specifically amitriptyline), anticonvulsants (specifically carbamazepine and pregabalin), and topical capsaicin were better than placebo for short-term pain control. In adding additional studies to the body of evidence, our findings were consistent for the drug categories of serotonin-noradrenaline reuptake inhibitors and the anticonvulsants gabapentin and pregabalin, and we did not identify additional studies for tricyclic antidepressants. Given that carbamazepine and amitriptyline had only one study with high risk of bias, we concluded that strength of evidence was insufficient for either of these individual drugs. Since we identified three new studies of atypical opioids in addition to the two described in Griebeler et al., and given the differences in mechanism of action from other opioids, we reanalyzed these studies separately, and found that this drug class was effective for the outcome of pain, but studies had many limitations (low strength of evidence). Another, more recent systematic review of pharmacologic treatments included open-label studies and concluded that many more drugs were effective for pain.^170^ Finally, the most recent comprehensive systematic review of pharmacologic treatments for all types of neuropathic pain (including other etiologies such as chemotherapy and trigeminal neuralgia^171^) included only blinded studies and had a few different conclusions, with a strong recommendation for gabapentin (in contrast to our findings that gabapentin had no effect) and a weak recommendation for lidocaine patches, where we identified no blinded studies for diabetic peripheral neuropathy. Adding to the Griebeler et al. review, we also synthesized data for paresthesia and numbness, but found that few studies addressed these outcomes. Griebeler et al. did not address quality of life, and we found insufficient strength of evidence across drug classes due to incomplete reporting. We also synthesized data on dropouts due to adverse effects and found that all drug classes of oral agents had at least some study arms with a >10% dropout rate due to adverse effects.

For nonpharmacologic approaches, the last comprehensive review including non-pharmacologic treatments ^172^ for diabetic peripheral neuropathy addressed literature through August 2008 and concluded that there were no effective treatments. Specifically, the review concluded that evidence was insufficient for alpha-lipoic acid or other supplements, that percutaneous electrical nerve stimulation should be considered, and that other methods should not be considered or had insufficient evidence. Our review found a number of new studies for non-pharmacologic approaches for the treatments addressed in Bril et al., as well as studies of new treatments. We concluded that spinal cord stimulation (although this has a risk of serious complications) and alpha-lipoic acid were effective for the outcome of pain (low strength of evidence), and transcutaneous electrical nerve stimulation and frequency-modulated electromagnetic stimulation were not effective (low strength of evidence); other treatments had insufficient evidence and require more research.

### Applicability

Trials were generally in populations of younger diabetic patients, with a mean age generally in the mid-50s, and results may not be applicable to populations of older diabetic patients who may be more susceptible to side effects, such as somnolence and dizziness. No studies reported subgroup analyses; patients with significant comorbidities may also have other sources of pain, in addition to diabetic peripheral neuropathy, and/or be more susceptible to side effects and drug interactions.

Few nonpharmacologic pain interventions were studied specifically for diabetic peripheral neuropathy, and evidence from treatments that are effective for other types of peripheral neuropathy or other chronic pain conditions (e.g., exercise, physical therapy) could also be relevant. Comparators were mostly limited to placebo or sham, limiting our ability to compare effectiveness among treatments or appropriateness for patient selection. Outcome synthesis was limited mainly to pain severity scores assessed at a single time point, which do not reflect the dynamic nature of pain; impact of pain on function; other symptoms of neuropathy, such as numbness and paresthesia; or overall impact of both benefits and side effects on patients’ quality of life. Lack of long-term outcomes and long-term adverse effect data is a particular limitation in this condition in a population with long-term, chronic issues.

### Limitations of the Review Process

This review updated a previous network meta-analysis by Griebeler et al., which had a number of limitations. Given the small number of head-to-head comparisons, some conclusions from the network meta-analysis were of questionable validity, particularly comparisons with only one study or from studies with high risk of bias. We did not update the network meta-analysis, given these issues, but rather conducted new meta-analyses where we identified additional studies with results that were not consistent with the network meta-analysis and had data that could be pooled. Given different findings from the direct and network meta-analysis from Griebeler et al. for opioids, the different mechanism of action of atypical opioids, and identification of three additional studies in this drug class, we separated out studies for atypical opioids and reanalyzed those data. Griebeler et al. also used standardized mean differences rather than a more clinically meaningful approach, and although these can be interpreted as small, moderate or large, they do not correlate with recommendations for interpretation of relative or absolute decreases in pain^173^ as clinically meaningful; findings may have been different with a different analytical method.

There are also a number of limitations of our review. We excluded studies including mixed populations of those with diabetic peripheral neuropathy and other types of neuropathy that did not report outcomes separately for diabetic peripheral neuropathy, which may have excluded some relevant data. In addition, given the heterogeneity of outcomes reported, we focused only on pain scales to synthesize results for pharmacologic agents, as done in previous systematic reviews. However, pain scales have many limitations as outcomes, as they evaluate pain only at one point in time and do not address other important aspects of pain treatment, such as improvement in function. In addition, some studies, particularly for non-pharmacologic treatments, had unusually high calculated effect sizes, potentially based on limitations of the reported data; we included these studies in our review but also evaluated results without them as a sensitivity analysis. We limited the review to pharmacologic and non-pharmacologic treatments evaluated in prior reviews or guidelines and available in the United States, to studies with at least 3 weeks of followup, and to studies with sham or placebo arms, wherever appropriate. This excluded some types of alternative treatments, very short-term studies, and studies where sham was possible but not used (especially for acupuncture). We also excluded non-English language publications and this limited our scope for acupuncture. Since we addressed the effectiveness of these interventions for diabetic peripheral neuropathy specifically, this review does not address the broader literature describing harms of these interventions in different conditions. This broader safety data, such as overall mortality from spinal cord stimulation,^174^ is therefore not included in this report.

### Strengths and Limitations of the Evidence Base

The strength of evidence was insufficient for many comparisons and outcomes owing to a paucity of studies, particularly for non-pharmacologic treatments. The lack of head-to-head comparisons for drugs limits comparative conclusions.^175^ Although drugs are often prescribed in combination with other drugs or in combination with non-pharmacologic treatments, we identified no studies on combinations of treatments. Trials were frequently downgraded in risk of bias assessment for not reporting blinding by participant and study personnel (performance bias) or outcome assessors (detection bias), and for incomplete outcome reporting. In addition, larger, higher-quality studies have almost all been conducted with new drugs with pharmaceutical company funding, and these were the only drugs with moderate strength of evidence: duloxetine and venlafaxine. For nonpharmacologic treatments, invasive procedures involving devices (i.e, spinal cord stimulators) are also more likely to have device manufacturer-sponsored trials.

The newest studies of pregabalin did not show effectiveness for pain compared to placebo. This may have been partly because these studies did not have a primary objective of evaluating the effectiveness of pregabalin for the outcome of pain, but there was also concern about reporting bias, given that none of the four studies found on Clinicaltrials.gov with results showed effectiveness for pain, and six additional studies from clinicaltrials.gov had not results. In addition, drugs with very large numbers of studies and enrolled patients (e.g., pregabalin) and pharmaceutical company funding would have greater power to show a statistically significant effect despite a small effect size than older drugs with few, small studies. For many of the studies and tapentadol in particular, there were concerns about study methodology inconsistent with standards for pain trials,^176^ including using nonstandard primary pain outcomes and withdrawal study methodology (of concern for studies of opioids, where withdrawal causes additional symptoms).

Studies often reported multiple assessment tools for a given outcome, which sometimes had conflicting results; the specific tools used and how they were reported was often inconsistent across studies. For pain, many different types of scales and composite tools were used, and pain severity was sometimes not reported separately. Other important issues, such as the impact of pain on function or quality of life (which includes patient-reported function), were inconsistently measured or reported; we analyzed data on quality of life, but were unable to draw conclusions due to incomplete reporting. All of these factors limited our ability to conduct meta-analyses in some cases or fully evaluate the impact of interventions.

Many studies were underpowered or did not recruit sufficient patients for the intended sample size, and withdrawal rates were often high, particularly in the few longer-term studies. The evidence base was also limited owing to the short duration of most studies. Most trials we identified were less than three months in duration and many were less than one month, despite the fact that these medications are used in clinical practice as chronic, long-term medications. Many studies were of insufficient duration to adequately assess long-term clinical outcomes, including continued effectiveness with progression of diabetic peripheral neuropathy; long-term side effects, such as weight gain; or long-term impact on function or diabetic complications. Adverse effects were often not reported for non-pharmacologic treatments and were often reported inconsistently for drugs, making synthesis difficult. Information from the broader literature on long-term use of these medications, particularly evolving data on the long-term harms of opioids^177^ in addition to the high dropout rates identified in our review, is needed for clinical decision making on benefit/harm ratios.

### Implications for Clinical and Policy Decisionmaking

Given that comparative effectiveness of pharmacologic options to each other and to non-pharmacologic options is very limited, and recent evidence focuses mainly on newly approved agents, clinical decisions regarding approach should take into consideration adverse effect profiles and patient preferences. Our findings generally support the effectiveness for the outcome of pain of the three drugs approved by the Food and Drug Administration for the symptom of pain in diabetic peripheral neuropathy: the serotonin-noradrenaline reuptake inhibitor duloxetine, the anticonvulsant pregabalin and the atypical opioid tapentadol. However, the effect size was small for pregabalin, new and unpublished studies did not show effectiveness for pain, and strength of evidence was low due to concerns about reporting bias. All these treatments also have substantial risks of adverse effects, which may be of particular concern for older patients with diabetes. Duloxetine had high rates of dropouts due to adverse effects, with rates of 17 to 20 percent in most study arms. In addition, pregabalin has a similar mechanism of action to gabapentin, and the two agents are often used interchangeably in clinical care, but Griebeler et al. and our updated review found that gabapentin was not more effective than placebo for the outcome of pain.

Few long-term studies exist for diabetic peripheral neuropathy. This is particularly important for the atypical opioids, which we found were more effective than placebo for the outcome of pain in short-term studies. However, these studies had significant methodological limitations. New guidelines and position papers now recommend against the use of opioids for chronic pain conditions, such as fibromyalgia and low back pain, given lack of evidence for long-term benefit and increasing evidence of serious risks, particularly abuse, misuse and overdose.^178^

Given the limitations of pharmacologic approaches, nonpharmacologic treatments could be of particular value. We found that the supplement alpha-lipoic acid was effective for pain (low strength of evidence), and there were few adverse effects. However, these studies were all conducted by the same investigator and had methodologic and reporting limitations. The only long-term study had a high dropout rate. Alpha-lipoic acid was not effective for numbness and paresthesia.

We also found that spinal cord stimulation was effective, but assessed strength of evidence as low, and it should be noted that this treatment has a risk of serious complications. Evidence on non-pharmacologic approaches all had methodologic limitations or a limited number of studies, with small sample sizes and inconsistent results for transcutaneous electrical nerve stimulation, lack of long-term effects for frequency-modulated electromagnetic stimulation, only one small study on cognitive behavioral therapy and no studies of exercise or physical therapy for pain.

### Future Research Needs

Many comparisons and outcomes that have low or insufficient evidence are future research needs. In particular, more studies are needed on lower-risk approaches, such as topical medications, and non-pharmacologic approaches, such as cognitive-behavioral therapy and exercise or physical therapy; for acupuncture, studies with sham arms are needed.

Larger studies with sufficient sample size and longer-term studies are also critical for future research. Followup of several weeks is insufficient for treatments that are often burdensome (e.g., electrical stimulation interventions that require frequent visits) or have significant adverse effects and dropout rates. The few longer-term studies often had very high dropout rates over time (e.g., for alpha-lipoic acid) and lower efficacy (e.g., for frequency-modulated electromagnetic stimulation).

We identified no studies that compared or combined pharmacologic and non-pharmacologic approaches; combinations of therapies would be critical to study further, as these approaches are often used together in clinical practice. Better assessment of adverse effects would also allow better evaluation of the benefit-risk balance, rather than just evaluation of effectiveness. Studies should also follow guidelines for pain intervention studies and evaluation of outcomes.^176^

### Conclusions

The anticonvulsants pregabalin and oxcarbazepine (low strength of evidence), the serotonin-noradrenaline reuptake inhibitors duloxetine and venlafaxine (moderate strength of evidence), the drug classes of tricyclic antidepressants (low strength of evidence) and atypical opioids (tramadol and tapentadol) (low strength of evidence), and the intradermal neurotoxin botulinum toxin (low strength of evidence) were more effective than placebo for reducing pain in diabetic peripheral neuropathy, although all oral drug classes had >10% dropout rates due to adverse effects. For nonpharmacologic treatments, we found no interventions with greater than low strength of evidence. Alpha-lipoic acid and spinal cord stimulation had low strength of evidence for the reduction of pain compared to placebo, but the latter has risk of serious adverse effects. Magnitudes of effect were generally moderate and all studies had deficits in quality. There were few studies evaluating non-pharmacologic interventions, such as exercise or cognitive therapy, for pain.

Additional studies evaluating longer-term outcomes, and those combining pharmacologic and non-pharmacologic approaches to maximize function, are needed to better inform clinical decisionmaking, patient choice, and clinical practice guidelines.