# Results for Key Questions (KQs) 1a and b

## Results of the Search

We included 62 studies (30 studies from an existing review and 32 newly identified studies reported in 37 articles. Figure 2 summarizes the search and selection of primary studies. (See Appendix C for list of citations excluded at full-text level, with reasons for exclusion.).

Figure 2 Summary of the literature search for primary studies: preventing complications

^*^ Reviewers did not need to agree on reason for exclusion.

^**^ Non-pharmacologic treatment options: foot care, surgical interventions, dietary strategies, lifestyle interventions, exercise and balance training

KQ = Key Question, RCT = Randomized Controlled Trial

Figure 2 describes the screening and review process of our literature search review for section KQ1a and KQ1b. 10,787 unique citations were identified. During the title and abstract screening process, 10,469 citations were excluded. In the full-text article screening process, a further 286 citations were excluded.

The breakdown of the included studies for KQ1a and b by study design is:

- KQ1a -12 studies (11 randomized controlled trials [RCTs] and 1 cohort study);
- KQ1b - Foot care interventions – 35 studies (20 RCTs and 10 cohort studies from an existing review and five newly identified studies (2 RCTs and 3 cohort studies);
- KQ1b - Lifestyle interventions - 1 RCT;
- KQ1b - Balance interventions - 6 RCTs and 1 cohort study;
- KQ1b - Exercise training interventions - 4 RCTs and 1 cohort study;
- KQ1b - Physical therapy interventions - 2 RCTs

The findings are summarized in Tables 5 to 11

Table 5 Summary of findings for pharmacologic treatment options

Outcome | Comparison | Number of Studies (N) | Findings | Strength of Evidence^*^
Foot ulcer | Intensive vs. standard glycemic control | Type 1 diabetes 2 RCTs (N=1329) | There was no significant difference between intensive vs standard glycemic control for prevention of foot ulcers (RR 0.32, 95% CI, 0.10 to 1.06 and 0.37, 95% CI 0.12 to 1.15) | Low
Foot ulcer | Intensive vs. standard glycemic control | Type 2 diabetes 2 RCTs (N=1326) | There was no significant difference between intensive and standard glycemic control. | Low
| Comparisons of individual medications either as monotherapy or in combination, to each other or to placebo | Type 1 diabetes None | NA | Insufficient
| Comparisons of individual medications either as monotherapy or in combination, to each other or to placebo | Type 2 diabetes 1 cohort study (N=23,395) | We could not draw conclusions based on insufficient evidence for prevention of foot ulcers between glargine insulin versus NPH insulin. | Insufficient
Lower extremity amputations | Intensive vs. standard glycemic control | Type 1 diabetes 1 RCT (N=1257) | There was no statistically significant difference between risk of lower extremity amputations in the intensive vs. standard glycemic control arms. | Low
Lower extremity amputations | Intensive vs. standard glycemic control | Type 2 diabetes 5 RCTs (N=9348) | There was a decreased risk of lower extremity amputations in the intensive vs. standard glycemic control arms. (Pooled RR 0.63, 95% CI 0.40 to 0.96). | Moderate
| Comparisons of individual medications either as monotherapy or in combination, to each other or to placebo | Type 1 diabetes None | NA | Insufficient
| Comparisons of individual medications either as monotherapy or in combination, to each other or to placebo | Type 2 diabetes 1 RCT (N=5238) | There was no effect of pioglitazone on risk of amputations compared to placebo. | Low
Quality of life | Comparisons of individual medications either as monotherapy or in combination, to each other or to placebo | Type 1 diabetes None | NA | Insufficient
Quality of life | Comparisons of individual medications either as monotherapy or in combination, to each other or to placebo | Type 2 diabetes 1 RCT (N=46) | We could not draw conclusions based on insufficient evidence on quality of life scores between exenatide and glargine. | Insufficient

* we graded only the key outcomes (falls, foot ulcer, amputation, and quality of life)

CI= confidence interval, RR = risk ratio, RCT = Randomized Controlled Trial, NA =Not applicable

Please see Appendix table E-1 -Strength of evidence table for domains

Table 6 Studies reporting harms of glucose lowering treatments in patients with type 1 and 2 diabetes at risk for diabetic peripheral neuropathy

Author, Year | Arm | Harm | N for Analysis | Time Point (s) | N of Patients with Harms | % of Patients with Harms
Jaiswal, 2015^37^ | Exenatide | Severe hypoglycemia | 22 | 18 months | 0 | 0%
Jaiswal, 2015^37^ | Insulin glargine | Severe hypoglycemia | 24 | 18 months | 1 | 4%
Jaiswal, 2015^37^ | Exenatide | Gastrointestinal problems | 22 | 18 months | 6 | 27%
Jaiswal, 2015^37^ | Insulin glargine | Gastrointestinal problems | 24 | 18 months | 4 | 17%
UKPDS^*^, 1998^47^ | Intensive glycemic control | Severe hypoglycemia | 2,729 | 10.7 years | NR | 1–2%
UKPDS^*^, 1998^47^ | Conventional treatment | Severe hypoglycemia | 1,138 | 10.7 years | NR | 0.7%
Steno-2, 2003^35^ | Intensive glycemic control | Severe hypoglycemia | 80 | 7.8 years | 12 | 15%
Steno-2, 2003^35^ | Conventional treatment | Severe hypoglycemia | 80 | 7.8 years | 5 | 6%
PROactive^39^ | Pioglitazone | Hypoglycemia | 2,605 | 34.5 months | 728 | 28%
PROactive^39^ | Placebo | Hypoglycemia | 2,633 | 34.5 months | 528 | 20%
VADT 2009 ^40^ | Intensive glycemic control | Hypoglycemia | 892 | 6 years | 76 | 9%
VADT 2009 ^40^ | Standard treatment | Hypoglycemia | 760 | 6 years | 28 | 5%
VACSDM 1995 ^41, 42^ | Intensive glycemic control | Severe hypoglycemia | 75 | 7.8 years | 5 | 6%
VACSDM 1995 ^41, 42^ | Standard treatment | Severe hypoglycemia | 78 | 7.8 years | 2 | 2.5%

* Trial reported the harms by drug class under intensive glycemic control arm instead of overall

Table 7 Summary of findings for foot care and surgical interventions for foot ulcers, amputation and quality of life

Outcome | Intervention | Number of Studies (N) | Findings | Strength of Evidence^*^
Foot ulcer | Integrated foot care | 4 Studies Previous SR: 3 RCTs and 1 cohort Newly identified study: None (N =350) | The previous review concluded that integrated foot care reduced foot ulcer incidence or recurrence. The reduction was ~20% across studies as compared to standard care or no podiatrist involvement. We did not identify new studies in our updated search | Low
| Self-management – Home-monitoring of foot temperature | 4 Studies Previous SR: 3 RCTs Newly identified studies: 1 RCT (N=583) | The previous review concluded that home monitoring of foot temperature reduced incidence and recurrence of foot ulcers compared with standard of care. The new study did not report statistically significant benefit but did not change the conclusion. | Moderate
| Self-management – Self-inspection and topical treatment on foot | 2 Studies Previous SR: 1 RCT Newly identified studies: 1 cohort study (N=360) | The previous review concluded that there was insufficient evidence to determine effectiveness of use of foot topical treatments on foot ulcers. The new study did not change the conclusion. | Insufficient
| Patient education | 4 Studies Previous SR: 2 RCTs Newly identified studies: 1 RCT and 1 cohort study (N=16943) | The previous review concluded that there was no reduction in ulcer recurrence from one time educational programs. The new studies did not change the conclusion. | Low
| Therapeutic footwear | 10 Studies Previous SR: 7 RCTs and 3 cohort studies Newly identified study: None (N=1913) | The previous review concluded that specific modalities of therapeutic footwear were effective in the prevention of a recurrent plantar foot ulcer compared with more standard-of-care therapeutic footwear. The risk reduction ranged from 4% to 45% across studies. We did not identify new studies. | Moderate
| Surgical interventions | 9 Studies Previous SR: 3 RCTs and 6 cohort studies Newly identified study: None (N=744) | The previous review concluded that surgical interventions (Achilles tendon lengthening, single or pan-metatarsal head resection and metatarsophalangeal joint arthroplasty) reduce ulcer recurrence risk in a range from 24% to 43% in some patients with initially non-healing ulcers when compared with non-surgical treatment. We did not identify new studies. | Low
Netten et al. did not assess amputation and quality of life
Amputation | Integrated foot care | 4 Studies 2 RCTs and 2 Cohort studies (n=27840) | We could not draw conclusions due to inconsistency of results between RCTs and cohort studies. | Insufficient
| Self-management | 1 RCT (N=85) | We could not draw conclusions due to insufficient evidence from one study. | Insufficient
| Patient education | 3 Studies 2 RCTs and 1 cohort study (N=16812) | The education programs did not change the occurrence of amputation in patients who received education program vs patients who did not receive education program. | Low
| Therapeutic footwear | 1 Cohort study (N=46) | We could not draw conclusions based on insufficient evidence from one study. | Insufficient
| Surgical interventions | 2 Cohort studies (N=168) | We could not draw conclusions due to inconsistent findings from a limited number of studies. | Insufficient
Quality of Life | Home-monitoring of foot temperature | 1 RCT (N=85) | We could not draw conclusions based on insufficient evidence from one study. | Insufficient
| Surgical interventions | 1 RCT (N=28) | We could not draw conclusions based on insufficient evidence from one study. | Insufficient

* we graded only the key outcomes (falls, foot ulcer, amputation, and quality of life)

Please see Appendix table E-2 -Strength of evidence table for domains

N= number of patients, NA = not applicable, RCT = Randomized controlled trial, SR: Systematic review,

Table 8 Summary of findings for lifestyle intervention

Outcomes | Comparison | Number of Studies (N) | Findings | Strength of Evidence
Quality of Life | Dietary Intervention: vitamin B12 alone vs. education on plant-based diet plus Vitamin B12 | 1 RCT (N=34) | We could not draw conclusions based on insufficient evidence from one study. | Insufficient

RCT =Randomized Controlled Trial

Table 9 Summary of findings for balance training and whole body vibration

Outcome | Comparison | Number of Studies (N) | Findings | Strength of Evidence^*^
Falls | Balance training vs control group | 1 RCTs (reported in 2 articles) (N=79) | We could not draw conclusions based on insufficient evidence from one study. | Insufficient
Falls | Whole body vibration | None | NA | Insufficient
Foot ulcer | Balance training | None | NA | Insufficient
Foot ulcer | Whole body vibration | None | NA | Insufficient
Quality of life | Balance training vs control group | 1 RCT (N=39) | We could not draw conclusions based on insufficient evidence from one study. | Insufficient
Quality of life | Whole body vibration | None | NA | Insufficient

* we graded only the key outcomes (falls, foot ulcer, amputation, and quality of life)

Please see Appendix table E-3 -Strength of evidence table for domains

NA = not applicable, RCT =Randomized Controlled Trial

Table 10 Summary of findings for exercise training interventions by outcome

Outcome | Number of Studies (N) | Findings | Strength of Evidence^*^
Falls | 1 RCT (reported in 2 articles) (N=79) | We could not draw conclusions based on insufficient evidence from one study. | Insufficient
Foot ulcer | 1 RCT (reported in 2 articles) 1 prospective cohort study (N=469) | We could not draw conclusions based on inconsistent findings from a limited number of studies. | Insufficient
Quality of life | 1 RCT (N=87) | We could not draw conclusions based on insufficient evidence from one study. | Insufficient

Note that table is organized by outcome, so some trials are listed more than once

* we graded only the key outcomes (falls, foot ulcer, amputation, and quality of life)

Please see Appendix table E-3 -Strength of evidence table for domains

RCT = Randomized Controlled Trial

Table 11 Summary of findings for physical therapy interventions

Outcome | Number of Studies (N) | Findings | Strength of Evidence^*^
Falls | None | NA | Insufficient
Foot ulcer | 1 RCT of weight-bearing vs non-weight-bearing activity (N=29) | We could not draw conclusions based on insufficient evidence from one study. | Insufficient
Quality of life | None | NA | Insufficient

* we graded only the key outcomes (falls, foot ulcer, amputation, and quality of life)

Please see Appendix table E-3 -Strength of evidence table for domains

RCT = Randomized Controlled Trial, NA = not applicable

## KQ1a Benefits and Harms of -Pharmacologic Treatment Options Focused on Glucose Lowering To Prevent Complications

### Key Points

- Glucose lowering strategies or specific glucose lowering medications did not prevent foot ulcers in patients with type 1 or type 2 diabetes (low or insufficient strength of evidence).
- Intensive glycemic control prevented lower extremity amputations more than standard glycemic control in patients with type 2 diabetes (moderate strength of evidence).
- Intensive glycemic control had higher rates of hypoglycemia than standard treatment.
- There was insufficient evidence to assess the effect of glucose lowering strategies on quality of life.

### Description of Included Studies

Twelve studies, reported in 15 articles, assessed the effectiveness of glycemic control and hypoglycemic medications to prevent the complications of diabetic peripheral neuropathy. Two studies, reported in three articles, included patients with type 1 diabetes,^31–33^ and 10 studies, reported in 12 articles, included patients with type 2 diabetes. ^34–45^

Of the 12 included studies, eleven were parallel arm RCTs^31, 32, 34, 35, 37, 39–45^ and one was a retrospective observational cohort study.^38^ The treatment duration of the RCTs ranged from 18 months to 12 years. The number of participants in the seven RCTs ranged from 46 to 5238 (with a median of 1173) and the observational study included 23,395 participants. Among the eleven RCTs, nine compared an intensive glycemic control strategy with standard care and did not describe the outcomes by specific medications.^31, 32, 34, 35, 40–45^ The two other RCTs included head-to-head medication comparisons. ^37, 39^ The seven RCTs ^35, 39, 40, 43, 45–47^ comparing intensive with standard glycemic control in patients with type 2 diabetes had similar populations, with mean age ranges between 50 and 60 years, except for the Japanese Elderly Diabetes Intervention Trial (J-EDIT) with a mean age of 72 years.^43^ These trials also differed in their glycemic control targets for the intensive treatment arms, with older trials having more modest targets (Hemoglobin A1c less than 7.5% in the 1997 Veterans Affairs Cooperative Study on Glycemic Control and Complications in Type II Diabetes [VACSDM]^41, 42^) and more recent trials being more intensive (Hemoglobin A1c less than 7.0% in the 2011 ADDITION study and less than 6.5% in the 2009 VADT). ^40, 45^ In addition, Steno-2 investigated blood pressure and lipid lowering along with tight glycemic control in the same arm, making it unclear which component led to the effect. ^36^

Four of the 11 RCTs comparing treatment strategies included post-trial observational followup, with durations ranging from 5.5 to 28 years, allowing for the ascertainment of long-term clinical outcomes, such as amputations and diabetic foot ulcers.^31, 32, 34, 35^ The Steno-2 trial reported amputation outcomes at two time points, at the end of the trial ^35^ and again after additional observational followup.^36^ The two RCTs that included comparisons of individual drugs were pioglitazone versus placebo^39^ and exenatide versus glargine insulin.^37^ The retrospective observational cohort study of over 23,000 participants compared glargine insulin versus NPH insulin.^38^

The overall risk of bias for these studies was low for seven trials, unclear for four trials and high for one cohort study. The trials had generally low risk of bias regarding the allocation concealment, random sequence generation, assessment of blinding by the outcome, selective outcome reporting, other sources of bias, and incomplete outcome data. The primary sources of bias in the cohort study were in the selection of participants, bias due to confounding, due to missing data, due to measurement of outcomes, and due to departures from intended interventions.

### Outcomes

#### Foot Ulcer

Five studies (4 RCTs and 1 cohort study) assessed foot ulcer.^31, 33, 38, 41, 43^ Two RCTs included patients with type 1 diabetes^31, 32^ and two included patients with type 2 diabetes,^41, 43^ comparing intensive with standard glycemic control strategies. One retrospective observational cohort study compared glargine insulin versus NPH insulin for the outcome of foot ulcer.^38^

For type 1 diabetes, the Stockholm Diabetes Intervention Study (SDIS) RCT reported 13 foot ulcers over 28 years of followup, three (8.6%) in the intensive glycemic control treatment arm and 10 (27%) in the standard treatment group arm. The calculated risk ratio for foot ulcers in the intensive versus standard glycemic control was 0.32 (95% CI, 0.10 to 1.06).^33^ The Diabetes Control and Complications Trial (DCCT)/Epidemiology of Diabetes Interventions and Complications (EDIC) trial had 8 years of followup, with four (0.6%) foot ulcers in the intensive glycemic control treatment arm compared with 11 (1.7%) in the standard treatment arm.^31^ The calculated risk ratio for intensive versus standard glycemic control was 0.37 (95% CI, 0.12 to 1.15). The Stockholm Diabetes Intervention Study (SDIS) and DCCT/EDIC trials both had continued observational followup and consistently reported decreased odds of foot ulcers in intensive versus standard glycemic control. The differences between intensive and standard care for the prevention of foot ulcers were not statistically significant, likely because the number of events was low despite long followup periods. We were unable to pool these results owing to the limited number of studies in patients with type 1 diabetes and similar interventions (Figure 3). We graded the strength of evidence as low for comparisons of intensive vs. standard glycemic control for the outcome of foot ulcer in patients with type 1 diabetes.

Figure 3 Calculated risk ratio for foot ulcers in the intensive versus standard glycemic control

%=percent; CI=confidence interval; N=sample size; p=p-value; RR=risk ratio

Figure 3 describes a forest plot of the calculated risk ratio for foot ulcers in studies that compared intensive versus standard glycemic control treatment.

For type 2 diabetes, the Veterans Affairs Cooperative Study on Glycemic Control and Complications in Type II Diabetes (VACSDM) and the Japanese Elderly Diabetes Intervention Trial (J-EDIT) RCTs reported foot ulcers.^41, 43^ In the VACSDM, one ulcer occurred (in the intensive treatment arm) in the total population of 153 over 7.8 years of treatment.^41^ The 3-year J-EDIT RCT reported a total of 12 foot ulcers or gangrene and that the between-arm difference was not statistically significant (p=0.56), but the event rates were not reported by arm^43^. We were unable to pool these results owing to the limited number of studies in patients with type 2 diabetes and because the J-EDIT study did not report foot ulcer rates by arm.

One cohort study including patients with type 2 diabetes reported a reduced hazard ratio (HR) for foot ulcers for patients taking glargine insulin versus NPH insulin (HR 0.61; 95% CI, 0.38 to 0.98).^38^ In this cohort study, the main outcome was diabetic foot ulcer and post-treatment between group glycemic control was not described. At baseline, the HbA1c was 8.0% in both groups.

We graded the strength of evidence as low for comparisons of intensive vs. standard glycemic control for the outcome of foot ulcer in patients with type 2 diabetes, because few included studies addressed the outcome of ulcers and the estimates were imprecise due to low event rates (Table 5).

#### Lower Extremity Amputation

Eight RCTs reported lower extremity amputations as an outcome.^31, 35, 39–41, 44, 45, 47^ The DCCT/EDIC RCT ^31^ included patients with type 1 diabetes and the seven other RCTs included patients with type 2 diabetes.^35, 39–41, 44, 45, 47^ Six RCTs reported lower extremity amputation in patients with type 2 diabetes comparing intensive versus standard glycemic control strategies^31, 35, 40, 41, 44, 45, 47^ and one trial, the Prospective Pioglitazone Clinical Trial in Macrovascular Events (PROactive) trial compared pioglitazone vs. placebo.^39^ Steno-2 reported amputations at two time points, at trial end (7.8 years) ^35^ and after an additional mean of 5.5 years.^36^

Figure 4 includes the five trials comparing intensive versus standard glycemic control. We excluded the Steno-2 from the meta-analysis because it had a mixed intervention approach^36^. The calculated risk ratios for amputations ranged from 0.55 to 3.12 and were not statistically significant (Figure 4). The five trials comparing the effectiveness of intensive glycemic control versus standard treatment indicated a decreased risk of lower extremity amputations in patients with type 2 diabetes (pooled RR 0.63 [95% CI, 0.40 to 0.96]) (Figure 4). Results from the five trials comparing the effectiveness of intensive glycemic control versus standard treatment indicate the clinical benefit of decreased risk of lower extremity amputations in patients with type 2 diabetes, with moderate strength of evidence. However, the total number of events, event rates and absolute risk differences were low despite long followup periods.

Figure 4 Calculated risk ratio for lower extremity amputations in the intensive versus standard glycemic control in patients with type 2 diabetes with diabetic peripheral neuropathy

%=percent; CI=confidence interval; N=sample size; p=p-value; RR=risk ratio

Figure 4 describes the meta-analyses of the calculated risk ratio for lower extremity amputations in studies comparing intensive treatment versus standard glycemic control. This is for patients with type 2 diabetes mellitus.

The DCCT/EDIC trial reported lower extremity amputation in patients with type 1 diabetes who received intensive glycemic control versus standard treatment with a calculated odds ratio of 0.40 (95% CI, 0.08 to 2.09), which was not statistically significant. We graded the strength of evidence as low for a lack of benefit of intensive vs. standard glycemic control, because only one trial assessed amputations in patients with type 1 diabetes and the point estimate was imprecise.

The PROactive trial compared pioglitazone (added to background medications) versus placebo in patients with type 2 diabetes and reported no difference in risk of amputations between the two arms [Hazard Ratio1.01 (95% CI, 0·58 to 1·73)].^39^

We graded the strength of evidence as low for comparison of pioglitazone vs. placebo, given that PROactive was a large trial (> 5000 participants) and it showed a lack of benefit for reducing lower extremity amputations due to diabetic peripheral neuropathy, although this was not the main objective of the study.

#### Quality of Life

One trial assessed the quality of life using global-neuropathy-specific quality of life (NeuroQOL).^37^ The RCT reported no difference in scores between the exenatide (change from baseline to 18 months −0.16±1.0) and glargine arms (change from baseline to 18 months 0.40±0.9) among patients with type 2 diabetes and diabetic peripheral neuropathy.

#### Harms

Six studies (reported in 7 articles) evaluated the risk of hypoglycemia.^35, 37, 39–42, 47^ RCTs evaluating intensive glycemic control versus standard treatment had greater event rates of hypoglycemia (range 0.6% to 6% in standard vs. 9% to 15% in intensive arms). The RCT comparing exenatide versus insulin glargine reported greater gastrointestinal problems in the exenatide group (27% vs. 17%) (Table 6).^37^

## KQ1b Benefits and Harms of Nonpharmacologic Treatment Options (Foot Care, Surgical Interventions, Lifestyle Interventions, Exercise, and Balance Training) To Prevent Complications

### Foot Care and Surgical Interventions

#### Key Points

- Patient education programs are not effective for reducing the incidence of foot ulcer with low strength of evidence.
- Integrated foot care (care given by one or multiple collaborating professionals treating patients at multiple occasions with multiple interventions) is effective in reducing foot ulcer incidence and/or recurrence with low strength of evidence.
- Home monitoring of foot skin temperature is effective for reducing foot ulcer incidence and recurrence with moderate strength of evidence.
- Specific modalities of therapeutic footwear are effective in prevention of recurrent plantar foot ulcers compared with standard-of-care therapeutic footwear with moderate strength of evidence.
- In patients with initially non-healing ulcers, Achilles tendon lengthening, single- or pan-metatarsal head resection and metatarsophalangeal joint arthroplasty are effective for reducing ulcer recurrence risk when compared with non-surgical treatment with low strength of evidence. However, Achilles tendon lengthening appeared to worsen physical functioning based on limited evidence.
- There was insufficient evidence to assess the effect of foot care and surgical interventions on quality of life.
- Adverse effects were not systematically assessed in studies.

#### Description of Included Studies

##### Summary of Studies Included in Existing Systematic Review

Netten and colleagues (2016) conducted a systematic review of interventions aimed specifically at the prevention of foot ulcers in at-risk patients with diabetes and included 74 studies (30 controlled studies and 44 non-controlled studies).We included 30 controlled studies (19 RCTs and 11 cohort studies) for this review from the Netten’s SR. Eligible studies included patients with diabetes mellitus type 1 or 2 at risk for foot ulceration, as defined in the International Working Group on the Diabetic Foot (IWGDF) guidance documents. Integrated foot care, self-management, patient education, therapeutic footwear, and surgical interventions were included and compared either with standard care plus other interventions or standard care alone. The primary outcomes of interest were first diabetic foot ulcer and recurrent diabetic foot ulcer. The secondary outcomes were amputation, A1c, ulcer incidence, ulcer severity, mortality, and hyperkeratosis. Thirty of the included controlled studies addressed outcomes of interest in our review (foot ulcer or amputation outcomes). The review authors used scoring sheets developed by the Dutch Cochrane Centre (www.cochrane.nl) to assess the risk of bias of included studies and assessed the quality of evidence for each question based on the risk of bias of included studies, effect sizes, and expert opinion. They rated the quality of evidence as ‘high’, ‘moderate’ or ‘low’.

The review authors concluded that the evidence base to support the use of specific self-management and footwear interventions for the prevention of recurrent plantar foot ulcers is consistent, but the evidence base is small for the use of other, sometimes widely applied, interventions and is practically nonexistent for the prevention of a first foot ulcer and non-plantar foot ulcer.

We assessed methodological quality of the Netten et al. review using the ROBIS tool.^27^ Overall risk of bias for this review was low. There were no concerns with the review process. The review conclusions appropriately reflect the results of the review.

##### Description of Newly Identified Studies

We updated the review by Netten et al. conducting a search for additional primary studies, as described in the Methods section. We identified five new studies: two parallel-arm RCTs^48, 49^ and three cohort studies.^50–52^ The cohort studies^50–52^ included patients with type 2 diabetes exclusively, while one RCT^48^ included patients with both type 1 and type 2 diabetes and the other RCT did not specify diabetes status of patients.^51^

#### Outcomes

We found studies evaluating incident or recurrent foot ulcer, amputation, and adverse events (e.g., dropouts, hypoglycemia, and cardiovascular events). We did not find any studies evaluating falls or perceived fall risk. The outcomes are presented by interventions. The results for the outcomes are summarized by foot care intervention (Table 7).

#### Foot Ulcer

We identified 34 studies that reported non-pharmacologic interventions and prevention of foot ulcers, including 26 RCTs and 8 cohort studies.

##### Integrated Foot Care

The review by Netten et al. defined integrated foot care as care given by one or multiple collaborating professionals treating patients at multiple occasions with multiple interventions. The authors identified three RCTs, one cohort, and one unpublished RCT.^53–56^. Integrated foot care provided by an endocrinologist and diabetes nurse,^53^ chiropody treatment ^55^, or multidisciplinary foot care given at least once every three months^56^ showed significant reductions in foot ulcer incidence or recurrence. The review by Netten et al. rated the strength of evidence as low.

In our updated search, we did not identify any new studies that evaluated the effectiveness of integrated care for foot ulcers.

##### Self-Management

Four studies, three RCTs from the Netten review and one newly identified RCT, evaluated the effectiveness of home monitoring of foot temperature on the incidence or recurrence of foot ulcers. Areas on foot that are likely to ulcerate have been associated with increased local skin temperatures due to inflammation. An infrared skin temperature device was used to provide objective information to patients to identify an early warning sign of inflammation and tissue injury.^57^ The review by Netten et al. found a significant reduction in foot ulcer incidence based on two studies with low risk of bias with moderate strength of evidence.^58, 59^ One RCT reported 12.2% patients ulcerated in the standard care group compared with 4.7% in the dermal thermometry group (OR 3.0; 95% CI, 1.0 to 8.5; P=.038)^59^ Another RCT reported the foot temperature monitoring group had significantly fewer incident diabetic foot ulcer (2.4% vs. standard therapy group 16%, P<0.05).

In addition, one RCT with low risk of bias included in the Netten review ^60^ reported a significant reduction in foot ulcer recurrence with instructions to perform structured foot inspection daily and to use an infrared skin thermometer after 15 months (8.5%), compared with either standard care plus instructions to perform daily foot inspection (30.4%, p=0.006) or with standard care alone (29.3%, p=0.008). One newly identified RCT with unclear risk of bias reported no statistically significant benefit from home-monitoring foot temperature on foot ulcer recurrence (7 ulcer recurrences out of 21 patients vs. 10 recurrences out of 20 patients).^60^ Figure 5 summarizes results from those studies.

Figure 5 Studies showing reduction in recurrence of foot ulcers in patients using home monitoring of foot temperature*

^*^ The figure shows results from 2 RCTs on recurrence. The study by Lavery et al., consisted of 3 study groups, including 2 separate comparisons.

CI=confidence interval; N=sample size; RR=risk ratio

Figure 5 describes the forest plot that shows a reduction in recurrence of foot ulcers in patients using self-monitoring of foot temperatures, in comparison to those using standard treatments or control arms. This was shown with calculated risk ratios.

Two studies evaluated the effectiveness of improving self-inspection of the feet through use of foot topical treatments on the outcome of foot ulcers. The Netten et al. review included one low risk of bias RCT of applying topical antifungal nail lacquer on a daily basis and found no benefit after 12 months as compared with standard care (5.9% vs. 5.6% ulcer incidence, p=0.9).^61^

In our updated search, we identified a retrospective cohort study^52^ that explored the predictors of diabetic foot ulcers among diabetic neuropathy patients. With moderate risk of bias, this study showed that application of moisturizing lotion to the feet was associated with higher incidence of subsequent foot ulcer (HR, 1.19; 95% CI, 1.04 to 1.36). This result may reflect the severity of disease of the patients who engaged in more foot lotion application. The study also reported no benefit from examining the bottom of feet or examining between toes on foot ulcer prevention.

A variety of foot care self-management programs have been evaluated showing heterogeneous effects. Use of home monitoring of the temperature of the feet was effective in lowering foot ulcer incidence. Improving self-inspections through topical application did not seem to be effective. We graded the strength of evidence as moderate for use of home monitoring of the temperature for foot ulcer incidence and insufficient for topical application.

##### Patient Education

Four studies evaluated the effectiveness of educational programs on diabetic foot ulcer and its complications. The Netten et al. review concluded that there was no reduction in ulcer recurrence from one-time single educational programs, based on two RCTs: one with high risk of bias^62^ and one with low risk of bias,^63^ and a low overall strength of evidence.

One newly identified RCT with high risk of bias^49^ reported no cases (0%) of foot ulcer in the group receiving the education program versus six cases (10%) in the standard care group which was not receiving the education program (p=0.012). A newly identified cohort study with low risk of bias showed a hazard ratio of 1.16 (95% CI, 0.95 to 1.41, p=0.055) comparing patients who did not attend an education program to those who did attend an education program.^50^ Results are thus inconsistent on the effect of education programs on foot ulcer prevention. We concluded that education programs were not effective for foot ulcer prevention based on the overall evidence.

##### Therapeutic Footwear

The Netten review included seven RCTs and three cohort studies on a variety of therapeutic footwear in preventing a first foot ulcer in at-risk patients with diabetes. Among those studies, RCTs reported custom-made digital silicon orthoses,^64^ intensive footwear therapy based on a prescription algorithm,^65^ shape or barefoot pressure-based custom-made insoles,^66^ or therapeutic shoes^67^ were effective in lowering the foot ulcer incidence. Cohort studies also reported decreased ulcer recurrence in patients wearing therapeutic sandals,^68^, and in patients who were beneficiaries of prescribed diabetic footwear compared to those wore their own footwear.^69^ However, selection bias cannot be ruled out and may be an important determinant of outcome. We did not find new studies in our updated search.

The review rated the strength of evidence as moderate for the use of various therapeutic footwear.

##### Surgical Interventions

The review by Netten et al.^18^ included three RCTs and six cohorts, evaluating a variety of surgical procedures to decrease foot ulcer recurrence risk in patients with diabetes with non-healing foot ulcers. The review authors concluded based on low strength of evidence that Achilles tendon lengthening, single- or pan-metatarsal head resection, and metatarsophalangeal joint arthroplasty appear to reduce foot ulcer recurrence in some patients with initially non-healing foot ulcers when compared with non-surgical treatment. Achilles tendon lengthening allows a patient to walk flat-footed without a bend in the knee. Single- or pan-metatarsal head resection includes either removing bone segments underlying the lesion or conservative treatment (i.e. relief of weight-bearing and regular dressing). Metatarsophalangeal joint arthroplasty prevents the surfaces of the joint toe from rubbing together. It is noted that surgical interventions are often performed in selected patients who did not respond well in previous treatments. Those patients may be at high risk of foot ulcer recurrence.^18^

#### Lower Extremity Amputation

Eleven studies, five RCTs and six cohorts, reported non-pharmacologic interventions and prevention of amputation outcomes. The Netten et al. systematic review did not grade the strength of evidence for amputation outcomes.

##### Integrated Foot Care

Four studies (2 RCTs and 1 cohort study from Netten et al. review and 1 newly identified cohort study) evaluated the effect of integrated foot care on amputation outcomes. One RCT with high risk of bias^53^ reported no amputation (0%) in patients who received standard care plus a foot care kit, were asked to perform daily foot care, had the involvement of a family member, attended hands-on workshops, received re-education every 3 to 6 months, and had monthly foot exams by an endocrinologist and a diabetes nurse versus two minor amputations (6.9%, p=0.46) in patients who received standard care plus foot assessment and 2 hours of diabetes education, including tips on foot care. Another RCT with low risk of bias^55^ reported two minor amputations (4%) in patients who received free chiropodist service versus one minor amputation (2%) in patients who received chiropodist service, if requested, but not free-of-charge. One cohort with high risk of bias reported 7 percent amputation with multidisciplinary foot care; podiatry every 3 months, or more often, if needed; re-education; and extra depth shoes versus 13.7 percent with education provided by the local endocrinologist or nurse and followup review examinations from local physicians every 3 months.^56^ One newly identified cohort study with low risk of bias^51^ reported a significant 20 to 25 percent reduction in lower extremity amputations and 30 to 35 percent reduction in major amputations if patients had prior podiatrist visits. We cannot draw conclusions about the effects of integrated foot care on amputation outcomes owing to the limited number of amputation cases and inconsistency of results between RCTs and cohort studies.

##### Self-Management

One RCT in the Netten et al. review with low risk of bias reported no cases of amputation in patients who received instruction to perform structured foot inspection daily plus infrared skin thermometer versus one case of amputation in patients who received instruction to perform structured foot inspection daily only.^59^. In our updated search, we did not identify any studies of self-management on amputation outcomes.

##### Patient Education

We identified three studies (1 RCT from Netten et al. review and 2 newly identified studies) evaluating effectiveness of education programs regarding diabetic foot disease and its complications. One RCT with low risk of bias in the Netten review reported no benefit from a single educational session about amputation (RR 1.0; 95% CI, 0.91 to 1.11). One newly identified RCT with high risk of bias did not report any amputations in either group.^49^ A cohort study^50^ with low risk of bias did not find a significant difference between patients who attended an education program and those who did not attend an education program about amputation. Results from all three studies suggested that education programs did not change the occurrence of amputation.

##### Therapeutic Footwear

One cohort study of therapeutic footwear with high risk of bias in the Netten et al. review reported no cases of amputation in 24 patients who accepted a prescription of orthopedic footwear and wore the footwear while being active versus two cases of amputation in 22 patients who did not ask for such a prescription.^70^ (p=0.13). In our updated search, we did not identify any studies of therapeutic footwear. We graded the strength of evidence as insufficient.

#### Surgical Interventions

The Netten et al. review identified two cohort studies evaluating surgical interventions on amputation outcomes. One cohort with low risk of bias reported no difference among patients who received multiple metatarsal head resections for multiple metatarsal head ulcers versus moisture-retentive dressing.^71^. Another cohort^72^ reported significant reduction in amputation rate in patients who received subtraction osteotomy ahead of metatarsal head ulcer to redress bone axis plus arthrodesis with staples versus conservative treatment (2.5% vs. 14.9%, p=0.04). We did not identify new studies in the updated search. We graded the strength of evidence as low.

#### Quality of Life

##### Home Monitoring of Foot Temperature

An RCT by Lavery et al ^57^ compared standard therapy with enhanced therapy that included a handheld infrared skin thermometer to measure temperatures on the foot. The investigators used the SF-36 to evaluate functional status and found no statistical differences in the SF-36 scores (total or subcategory scores) either between groups or, in the pre- and post- study evaluations, within groups. We graded the strength of evidence as insufficient.

##### Surgical Interventions

In our updated search, we identified one 8-month RCT^73^ with high risk of bias that evaluated Achilles tendon lengthening (ATL) after total contact casting (TCC) on foot ulcer recurrence, quality of life using SF-36, and perceived disability. Achilles tendon lengthening is performed in high-risk patients with diabetes, peripheral neuropathy, and a history of recurrent ulcers. The study reported a worse score in SF-36 physical summary after Achilles tendon lengthening as compared with- TCC only (p=0.035), while no difference between the interventions in other physical performance outcomes was found. There was insufficient evidence to address the effectiveness of Achilles tendon lengthening for quality of life after total contact casting.

#### Harms

The prior review^18^ did not assess adverse effects. Two of the five newly identified studies reported adverse effects.^48, 50^ One high risk of bias study^48^ reported no dropouts in the control group and three dropouts in the intervention group. Statistical testing was not reported. Another study^50^ with low risk of bias reported glycemia-related emergency department visits and found no difference between the two groups [n=43 (0.5%) in attendees vs. n= 44 (0.6%) in non-attendees; RR 1.02; 95% CI, 0.58 to 1.77]. The same study also reported a significantly increased risk of cardiovascular events in patients who attended an education program versus patients who did not attend an education program (16.66 per 1000 person-year vs. 15.14 per 1000 person-year; 99% CI, 0.9 to 1.31; p=0.036). Adverse effects were not systematically documented in clinical trials. We were unable to draw conclusions, as most studies did not report harms.

### Lifestyle Intervention

#### Key Point

- There was insufficient evidence from one study on lifestyle intervention and any of the diabetic peripheral neuropathy complications.(Insufficient strength of evidence)

#### Description of Included Studies

Only one 20-week pilot randomized trial assessed the effectiveness of dietary interventions using a plant-based diet and Vitamin B12 to improve quality of life with diabetic peripheral neuropathy. ^74^ This was a single-center study conducted in the United States. The trial included 34 patients with type 2 diabetes. The risk of bias was high. The main potential cause of bias was lack of allocation concealment and blinding; details of allocation and blinding were not reported.

#### Outcomes

##### Quality of Life

One trial assessed the benefit of a plant-based diet on health-related quality of life using the Norfolk Quality of Life Questionnaire.^74^ The trial reported no significant difference in total score (difference of mean change: −4.0; 95% CI, −15.1 to 7.1) of the Norfolk Quality of Life Questionnaire between the intervention arm that received nutrition education about a plant-based diet plus a B12 supplement and the comparison arm that received B12 only. We could not draw conclusions due to insufficient evidence from one study (Table 8).

##### Harms

No harms data were reported.

### Balance Training and Whole Body Vibration Interventions

Definition: In this review, we used the term balance training to refer to exercises designed to improve balance, with better control of movement of center of mass and improved coordination of lower extremities.^75–77^ measured with and without quantitative devices, force plates, or platform systems (Biodex); using established balance scales (TUG, Berg balance, FRT); and under static and dynamic conditions. Computerized balance devices enable computation of anterior-posterior stability, medio-lateral stability, and overall stability.

#### Key Points

- Balance training did not improve the outcomes of physical activity or perceived fall risk.
- Evidence was inconsistent for the effect of balance training on balance outcomes.
- There was insufficient evidence to assess the effect of balance training and whole body vibration interventions on quality of life.

#### Description of Included Studies

We identified seven studies (reported in 8 articles) that assessed the effect of balance training and/or whole body vibration on balance outcomes, physical activity, perceived fall risk, falls, and quality of life. Balance interventions include static, dynamic, and progressive balance exercises, generally supervised by a physical therapist, and may include simulation training. Whole body vibration applies vibratory stimuli with the aim of activating leg musculature and improving balance; whole body vibration was conducted in these studies with an applied frequency of 30 Hz and an amplitude of one to three millimeters.

Five RCTs (reported in 6 articles) and one non-randomized study compared balance training with a control group (no intervention) ^75–81^ (one trial also included simulation as part of the training^78^). One RCT compared whole body vibration therapy with a control group^82^ and one RCT included combined whole body vibration and balance training, balance training alone, and control arms.^76^

The number of participants in the included studies ranged from 20 to 79, with a total of 320 participants in all studies. Duration of followup ranged from 3 weeks to 12 months. The average age of the participants ranged from 57 to 77 years and most studies included a percentage of female participants at more than 50 percent. Three RCTs studied patients with type 2 diabetes^75, 78, 82^ and one RCT studied patients with both type 1 and 2 diabetes^79, 80^ The remaining two RCTs and the non-randomized trial did not specify the type of diabetes patients.^76, 77, 81^

The overall risk of bias for most of the studies was low. Bias was unclear in some studies owing to poor reporting regarding allocation concealment, random sequence generation, assessing blinding by the outcome, and other sources of bias. Studies generally had a low risk of bias regarding incomplete outcome data and selective outcome reporting.

One trial also included exercise training components and, therefore, physical activity outcomes for this study are included in the exercise training section.^79, 80^

#### Outcomes

##### Dynamic Balance and Stability

Five trials (reported in six articles) and one non-randomized study assessed dynamic balance and stability outcomes, measured using the Berg Balance Scale (BBS), Timed Up and Go Test (TUG) and Functional Reach Test (FRT). Five studies evaluated the effects of balance training^76–82^ one trial evaluated whole body vibration with balance training ^76^ and one trial evaluated whole body vibration alone.^82^

For balance training, standardized mean difference could not be calculated for many of the studies due to incomplete data, so results from the scales are provided. Four of the trials, reported in five articles, reported effects on the BBS.^76–80^ The difference between the balance training group and the control group for the mean change from baseline ranged from 0.2 to 2.0 on a 0–56 scale, with the direction of effect favoring the intervention group.

Five of the balance training trials, reported in six articles, reported effects on the TUG.^76–80, 82^ Four trials, reported in five articles, compared TUG outcomes in balance training and control groups.^76–80^ The mean difference between the balance training group and the control group for the mean change from baseline ranged from −2.12 to 0.1, (the minimal clinically important difference is 1–2 seconds), with the direction of effect favoring the intervention group.

Three of these balance training studies (2 RCTs and one non-randomized study) also reported effects on the Functional Reach Test (FRT).^76, 77, 81^ The difference between the balance training group and the control group ranged from 0.4 to 8.97, with the direction of effect favoring the intervention group. Evidence was imprecise and inconsistent for the effect of balance training on balance outcomes.

For whole body vibration, results are presented as standardized mean difference. The study combining balance training with whole body vibration reported effects on the Berg Balance Scale (BBS) with a standardized mean difference of 1.77 (95% CI, 1.01 to 2.53), Timed Up and Go Test (TUG) with an standardized mean difference of −1.95 (95% CI, −2.74 to −1.17) and Functional Reach Test (FRT) with an standardized mean difference of 1.72 (95% CI, 0.967 to 2.48), all with the direction of effect favoring the intervention group.^76^ The study of whole body vibration alone reported effects on the Timed Up and Go Test (TUG) ^82^; with an standardized mean difference of −2.47 (95% CI, −3.63 to −1.31), with direction of effect favoring the intervention group (negative standardized mean difference denotes less time required to complete task). One of the studies also reported effects on the, with the direction of effect favoring the intervention group. Given the heterogeneity of interventions (whole body vibration alone vs combined with balance training), we were unable to draw any conclusions.

##### Physical Activity

For balance training, three trials (reported in four articles) assessed physical activity outcomes such as 6-minute walk test; 10-meter walk test; total daily steps; and time spent sitting, standing, and walking.^75, 77, 79, 80^

A RCT of balance training (reported in two articles) assessed 6-minute walk outcomes in balance training and control groups.^79, 80^ The effect size was −0.04 (95% CI, −0.52 to 0.43) in the direction favoring the control group.

Another RCT of balance training assessed a 10-meter walk test.^77^ The standardized mean difference was −0.51 (95% CI, −1.16 to 0.13), direction of effect favoring the intervention group.

Two of these trials of balance training, reported in three articles, also assessed the effect on total daily steps.^75, 79, 80^ The effect size for the difference between groups in change in activity from baseline at 12 months ranged from 0.15 to 0.16 in the direction favoring the intervention group, with similar results at earlier timepoints.

One of these RCTs of balance training also assessed the effect on time spent sitting, standing, or walking during a 48-hour period.^75^ The effect size was 0.01 for sitting, 0.04 for standing, and 0.14 for walking (95% CI not given, but not statistically significant).

Based on the lack of findings of effectiveness, we concluded that balance training did not improve physical activity.

Studies of whole body vibration did not evaluate physical activity.

##### Perceived Fall Risk

Three RCTs (reported in four articles) and one non-randomized study^75, 78–81^ assessed perceived fall risk among participants, each study using a different scale of assessment. The heterogeneity in assessment outcomes precluded pooling of data.

Two RCTs, reported in three articles, evaluated the effect on the Falls Efficacy Scale (FES)^79, 80^ or FES-I (international version, modified to be more culturally and socially sensitive)^75^ score between balance training and control groups.^75, 79, 80^ The standardized mean difference for FES/FES-I ranged from −0.13 to zero.

Another RCT of balance training reported the effect on the Fall Risk Index, with a standardized mean difference of −1.21 (95% CI −1.94 to −0.48), in the direction favoring the intervention group.^78^

A non-randomized study assessed the effect on the Activities-specific Balance and Confidence (ABC) scale.^81^ The standardized mean difference was 0.42 (95% CI, −0.58 to 1.41) in the direction favoring the intervention group.^81^ Based on the lack of findings of effectiveness, we concluded that balance training did not improve perceived fall risk.

Studies of whole body vibration did not evaluate perceived fall risk.

##### Falls

For balance training, one RCT, reported in two articles, assessed falls per 1000 person-days of follow at 12-month followup.^79, 80^ There was no statistically significant difference in falls between the balance training group and the control group (2.06 versus 2.02 falls/1000 person-days, respectively). We could not draw conclusions due to insufficient evidence from one study.

No studies of whole body vibration evaluated falls (Table 9).

##### Quality of Life

For balance training, one RCT reported the outcome of quality of life.^75^ It reported the SF-12 physical component score; standardized mean difference was 0.012 (95% CI, −0.65 to 0.68), in the direction favoring the intervention group. We could not draw conclusions due to insufficient evidence from one study.

No studies of whole body vibration evaluated quality of life (Table 9).

##### Harms

For balance training, one study reported no dropouts owing to adverse effects in either group.^75^ In another study, one of the participants in the intervention group dropped out owing to ankle pain.^81^

### Exercise Training Interventions

Definition: Exercise training is defined as maintaining or increasing physical activity for the purpose of fitness and can be done solo or in a group. For this review, fitness activities which did not include supervision by physical therapists were classified in the exercise category.

#### Key Points

- Exercise training did not improve the outcomes of physical activity or perceived risk of fall.
- There was insufficient evidence to assess the effect of exercise training on falls, foot ulcer, amputation, and quality of life.

#### Description of Included Studies

Five studies, reported in six articles, assessed the effect of exercise training.^79, 80, 83–86^

Exercise training interventions included treadmill training^83, 85^ and/or muscle strengthening,^79, 83, 84^ with sessions ranging from two to six times per week and up to 360 minutes total time per week.^85^

Four studies, reported in five articles, were parallel arm RCTs comparing exercise training interventions with a control condition.^79, 80, 83–85^ One study was a prospective cohort comparing three study groups classified by self-reported physical activity level (number of self-reported hours per day of any weight-bearing activity, including standing, walking, or more active).^86^

The number of participants in the five studies ranged from 27 to 390, with a total of 638. Duration of followup ranged from 4 weeks to 2 years. All studies except one included patients with type 2 diabetes mellitus, but the diabetes type was not specified in the cohort study.^86^ The average age of the participants ranged from 54 to 73 years of age. Two trials included participants with a mean BMI in the obese category.^79, 80, 83^

The overall risk of bias for trials was low. These trials had generally low risk of bias regarding random sequence generation, blinding of outcome assessors, and selective outcome reporting. However, the risk of bias was unclear regarding the allocation concealment, incomplete outcome data, and other source of bias. The overall risk of bias for the cohort study was graded as moderate. The primary sources of bias were in the selection of participants and bias due to confounding.

We also included one of the RCTs, reported in two articles, in the balance training section, as the study intervention also aimed to improve balance.^79, 80^ Another RCT included exercise and physical therapy components but is only described in this section given overlap in outcomes.^84^

#### Outcomes

##### Physical Activity

Two RCTs, reported in three articles, assessed the effect of exercise training on the physical activity outcome using the distance traveled in the 6-minute walk test and total daily steps.^79, 80, 83^

For the 6-minute walk test, the mean difference from baseline between groups ranged from −0.04 meters (95% CI, −0.52 to 0.43)^80^ to 0.35 meters (95% CI not reported, but was not statistically significant).^83^

For total daily step counts, the effect size for the difference between groups in change in daily steps from baseline to 12 months was 0.16 (95% CI, −0.31 to 0.63), with similar results at earlier time points.^79, 80^ Based on the lack of effect, we concluded that exercise did not improve physical activity outcomes.

##### Perceived Fall Risk

Two studies, reported in three articles, used different scales to assess perceived fall risk among participants.

One RCT, reported in two articles, evaluated the difference in the Falls Efficacy Scale (FES) score between exercise training and control groups.^79, 80^ Standardized mean difference was 0 (95% CI, −0.44 to 0.44).

Another RCT used the ABC scale to assess an exercise training group versus a control group.^84^ The reported intervention effect size was 0.5 (95% CI not reported, p<0.05) in the direction favoring the intervention group.

Based on the lack of consistent findings, we were unable to draw any conclusions on the effect of exercise training on perceived fall risk.

##### Falls

One RCT(reported in two articles) assessed falls per 1000 person-days after 12 months of followup.^79, 80^ The difference in falls between the exercise training group and the control group was 2.06 versus 2.02 falls/1000 person-days, respectively, and was not statistically significantly different. We could not draw conclusions due to insufficient evidence from one study (Table 10).

##### Foot Ulcer

One RCT (reported in 2 articles) and one prospective cohort study assessed outcomes of foot ulceration.^79, 80, 86^

The RCT evaluated the effect of exercise training on foot ulcers.^79, 80^ At the end of 12 months, the incidence rate of all foot ulcers, defined as any disruption of skin surface at or below malleolus, was not statistically different in the intervention group when compared to the control group (0.63 versus 0.51 lesions/person-year at risk; rate ratio 1.24; 95% CI, 0.70 to 2.19). The incidence rate of full thickness ulcers was similar in both groups (0.21 versus 0.22 lesions/person-year at risk; rate ratio 0.96; 95% CI, 0.38 to 2.42).

One prospective cohort study evaluated outcomes of foot ulceration in three participant groups based on their daily physical activity: least active (less than 4.5 active hours/day), moderately active (4.5 to 7.5 active hours/day), and most active (more than 7.5 active hours/day). The incidence rate of re-ulceration at 2 years followup was statistically significantly higher in the least active group when compared to the two other groups [16.5% in the least active group with OR 1 (95% CI not reported), 13.4% in the moderately active group with OR 0.66 (95% CI, 0.36 to 1.19), and 13% in the most active group with OR 0.36 (95% CI, 0.16 to 0.82)].^86^ We graded the strength of evidence as insufficient (Table 10).

##### Quality of Life

One RCT assessed the outcome of quality of life between exercise and control groups. ^85^ Standardized mean difference was −4.9 (95% CI, −5.74 to −4.06), in the direction of effect favoring the intervention group. We could not draw conclusions due to insufficient evidence from one study (Table 10).

##### Harms

Only one RCT reported on harms and only for risk of severe hypoglycemia: 23.4 percent of participants in the control arm experienced severe hypoglycemia compared to 5 percent in the exercise training arm. The hypoglycemic events in the control group were insulin/oral hypoglycemic agent-related and in the intervention group, the events were exercise-related. ^85^

### Physical Therapy Interventions

Definition: Physical therapy was defined as any physical and therapeutic activity performed under the guidance of a physical therapist.

#### Key Points

- No physical therapy intervention studies evaluated the outcomes of perceived fall risk, falls or quality of life.

#### Description of Included Studies

Two RCTs assessed the effect of physical therapy interventions in diabetic peripheral neuropathy.^87, 88^ One RCT compared two types of physical therapy exercises to improve physical activity: weight bearing (n=15) versus non-weight bearing (n=14), each conducted in-group exercise sessions supervised by a physical therapist.^87^ The other RCT assessed Thai foot massage to improve balance, modified foot massage performed by traditional Thai massage therapist, (n=30) compared to a non-massage control intervention (n=30).^88^ One trial reported followup of 12 weeks^87^, and the other trial reported a mean followup of 2 weeks^88^ The average age of the participants was 64 years in one trial,^87^ and 58 years in the other trial.^88^ One trial included participants with mean BMI in the obese category^87^ and one included participants with mean BMI in the overweight category.^88^ Overall risk of bias in these trials was low.

#### Outcomes

##### Balance

The RCT comparing Thai foot massage to control used the TUG instrument to assess the impact on balance.^88^ The standardized mean difference was −0.46 (95% CI, −0.46 to −0.82), with the direction of effect favoring the intervention group^88^.

##### Physical Activity

One trial reported data on physical activity. The RCT comparing weight bearing to non-weight bearing physical activity measured outcomes with average daily steps and the 6-minute walk test.^87^ The standardized mean difference was 0.66 (95% CI, −0.09 to 1.41) with the direction of effect favoring the weight-bearing group. The standardized mean difference for the 6-minute walk test was 0.28 (95% CI, −0.45 to 1.01) with the direction of effect favoring the weight-bearing group.^87^

Given the limited number and heterogeneity of studies and interventions, we were unable to draw any conclusions.

##### Falls/Perceived Fall Risk

No studies reported data on falls or perceived fall risk.

##### Foot Ulcer

One RCT assessed outcomes of foot ulceration.^87^ There was one ulcer in the weight-bearing exercise group compared with three ulcers in two participants in the non-weight-bearing exercise group. We could not draw conclusions due to insufficient evidence from one study (Table 11).

##### Quality of Life

No studies reported quality of life.

##### Harms

No harms data were reported.

## Discussion

### Key Findings and Implications

We identified 62 studies (30 studies from a prior systematic review, and 32 newly identified studies) that addressed the benefits and harms of pharmacologic and non-pharmacologic treatment options to prevent the complications of diabetic peripheral neuropathy in patients with type 1 and type 2 diabetes. We assessed glycemic control (including individual hypoglycemic medications and the effect of lowering blood glucose), foot care, surgical interventions, lifestyle interventions, balance training, exercise training, and physical therapy. Our review focuses on complications of diabetic peripheral neuropathy, specifically diabetic foot ulcers, lower extremity amputations, falls, physical activity level, perceived risk of falling, and quality of life.

Our review showed the benefit of intensive versus standard glycemic control for preventing lower extremity amputations in patients with type 2 diabetes. However, amputation was not the primary outcome in any of the included studies and the event rates were very low. We identified only one large RCT conducted in type 1 diabetic patients and this study reported no difference for intensive compared to standard glycemic control for the prevention of lower extremity amputations.^89^

There was no benefit for diabetic foot ulcers for glycemic control versus standard control for patients with either type 1 or type 2 diabetes, although the number of events were low. Only one RCT assessed the effectiveness of one glucose-lowering medication compared to another glucose-lowering medication for prevention of diabetic foot ulcers and lower extremity amputations and this study found no difference in benefit. Intensive glycemic control had higher rates of hypoglycemia than standard treatment.

For foot care interventions aimed at the prevention of foot ulcers and amputations, moderate strength of evidence supported home monitoring of foot skin temperature for the reduction of recurrence of diabetic foot ulcers. However, three out of the four studies were done by the same investigators; additional studies by different investigative teams are needed to confirm reproducibility. Integrated foot care interventions were also shown to prevent ulcer recurrence, but the assessment of the effect of patient education about foot care on foot ulcer prevention was inconclusive. The review we updated concluded that specific modalities of therapeutic footwear are effective in the prevention of a recurrent plantar foot ulcer compared with more standard-of-care therapeutic footwear. For amputation outcomes, evidence was not consistent regarding benefit from integrated foot care, as the review by Netten et al. did not show significant difference while one newly identified study reported significant reduction. The previous systematic review ^18^ reported no benefit from an education session and the findings from newly identified studies were consistent with this previous conclusion.

Results were inconsistent for the effect of balance training on specific balance measures. Balance training did not improve outcomes of physical activity or perceived risk of falling. Exercise also did not improve physical activity or perceived risk of falling. Data were insufficient to assess the effect of physical therapy alone on physical activity levels. No physical therapy intervention studies evaluated the outcome of perceived risk of falling. The strength of evidence for physical therapy, exercise, or balance training was insufficient for falls outcome.

We found few studies that assessed the benefits of glycemic control or foot care for improving quality of life. The strength of evidence was insufficient to provide conclusions favoring one treatment over another for improving quality of life for patients with diabetic peripheral neuropathy.

### Findings in Relationship to What Is Already Known

Our review confirms the conclusions from three recent systematic reviews that addressed intensive versus standard glycemic control for the prevention of lower extremity amputations in patients with type 1 and type 2 diabetes. ^89–91^ In contrast with these reviews, our review also assessed the prevention of foot ulcers when reported in the included studies. However, diabetic foot ulcers are likely under-reported owing to the possibility of limited outcome ascertainment if the ulcer had healed prior to the data collection visit and because it was not a primary or adjudicated outcome in any studies. Because diabetic foot ulcer is often in the causal pathway leading toward gangrene and the indication for lower extremity amputation, the reduction in ulcer rates was consistent with the direction for the prevention of lower extremity amputation, a more distal outcome. Overall, the preponderance of evidence supports intensive glycemic control in patients with type 2 diabetes to prevent lower extremity amputations. Few studies had evidence supporting intensive glycemic control for ulcer prevention in patients with type 1 and type 2 diabetes. The recent guidelines from the Society for Vascular Surgery and collaborative professional organizations included foot ulcer prevention in its recommendations for the prevention of amputation, and recommended achieving a hemoglobin A1c of seven percent or lower (intensive control) to reduce foot ulcer incidence. ^92^ Although our review was unable to quantify the long-term risks associated with intensive glycemic control, the ACCORD trial has raised significant concerns about very intensive glycemic control (hemoglobin A1c goal less than 6%) strategies and increased cardiovascular disease mortality.^93^

We updated a recent systematic review by Netten et al. on foot care interventions to prevent ulcers and lower extremity amputations.^18^ Evidence from this previous systematic review supports an integrated foot care program that involves podiatrist care for reducing foot ulcer recurrence.^18^ This is consistent with the recommendation from the Society for Vascular Surgery that patients with diabetes should undergo annual interval foot inspections by physicians, podiatrists or advanced practice providers with training in foot care. Regarding foot care, home-monitoring of foot skin temperature also reduces foot ulcer recurrence based on 2 RCTs. ^48, 60^ There was no benefit from patient education on foot ulcer prevention, similar to other reviews. The previous systematic review by Netten et al. also concluded that specific modalities of therapeutic footwear could be effective in the prevention of a recurrent plantar foot ulcer at selected high risk patients; we did not identify any new studies for these interventions. However, the Society for Vascular Surgery recommended against the routine use of specialized therapeutic footwear in average-risk diabetic patients, while it did recommend using custom therapeutic footwear in high-risk diabetic patients, including those with significant neuropathy, foot deformities, or previous amputation.^92^ Finally, Netten et al. reported that Achilles tendon lengthening, single- or pan-metatarsal head resection, and metatarsophalangeal joint arthroplasty appear to reduce ulcer recurrence risk in selected patients with initially non-healing ulcers.^18^ In our updated search, one new study reported statistically significantly worsened quality of life (as measured using the SF-36 physical function summary score) after Achilles tendon lengthening versus total contact casting and no difference in ulcers. ^56, 94^ The report from the Society for Vascular Surgery did not address Achilles tendon lengthening, single- or pan-metatarsal head resection, or metatarsophalangeal joint arthroplasty for ulcer prevention. ^92^

Finally, our review is the first of which we are aware to assess the outcomes of falls and perceived risk of falling in patients with type 1 and 2 diabetes and diabetic peripheral neuropathy.

### Applicability

Our results are highly applicable to patients with type 2 diabetes and with diabetic peripheral neuropathy. For the complications of diabetic peripheral neuropathy, we graded the body of evidence for outcomes (ulcers, amputations, falls and quality of life) which are clinically important as well as important to patients. Diabetic foot ulcers are likely under-reported in these studies and few studies assessed perceived risk of falling, an outcome important to patients. The studied populations were typically those with type 2 diabetes older than 50 years of age, so the findings may not apply to younger patients or those with type 1 diabetes. Several trials comparing intensive versus standard glycemic control followed the study population with observational followup, enabling ascertainment of longer-term outcomes, such as amputation and ulcers, in patients with longstanding diabetes.

### Limitations of the Review Process

We did not include non-English studies. However, we did not limit our searching by language and, where possible, screened non-English language articles for eligibility. We do not feel that the exclusion of the non-English studies influenced our conclusions or ability to draw conclusions. We excluded studies of mixed populations with diabetic peripheral neuropathy and other types of neuropathy that did not report outcomes separately for diabetic peripheral neuropathy. This may have excluded some relevant data.

For foot care, we identified a relevant high-quality review meaning that we did not have to complete a systematic review de novo. However, there are challenges in using a prior review. For instance, there are some areas where we do not have the same level of detail as we would if we had completed the assessment and abstraction of all of the primary studies.

Finally, our review questions focused on patients with a diagnosis of type 1 or type 2 diabetes and so we make no conclusions about the prevention of neuropathy, progression to more severe neuropathy or neuropathic complications (e.g., foot ulcers and amputations) in patients with impaired glucose tolerance.

### Strengths and Limitations of the Evidence Base

Despite the clinical importance and importance to patients of falls, we identified few studies that assessed the effect of pharmacologic and non-pharmacologic interventions on falls and perceived risk of falling in patients with diabetic peripheral neuropathy.

The major strength of the evidence base is the availability of long-term followup in RCTs assessing diabetic foot complications in patients with type 1 and 2 diabetes. Because foot ulcer and amputations were secondary outcomes in these studies, the limitation of the evidence is that many ulcers, and possibly amputations, were missed owing to the need to review medical records and a lack of standard outcome ascertainment protocols. Foot ulcer and amputation event rates were low resulting in small absolute risk differences between groups. Despite these small absolute differences, foot ulcers and amputation are clinically relevant and patient-important outcomes, and despite lack of statistical significance, could be clinically significant. We identified few studies of individual glucose lowering medications that reported the outcomes of foot ulcer or amputation. In addition, few studies assessing glycemic control reported on other patient reported outcomes, such as quality of life.

For foot care and surgical interventions, the major limitation is that the types of therapeutic footwear and surgical interventions varied across studies. It is difficult to make conclusions about the effectiveness of a specific intervention based on a few number of studies. In addition, surgery is sometimes a last-resort approach. Patients with diabetes who receive surgeries are often selected because of previously failed conservative treatment and therefore at high risk of foot ulcer recurrence. Furthermore, most of the cohort studies were considered high risk of bias due to unblinded outcome assessment by investigators.^18^

The limitations for the evidence base on balance, exercise, and physical therapy interventions were the reliance on intermediate measures of balance, falls, and function. It was not clear how well these measures correlate with long-term benefits and with the patient-important outcomes of falls and the ability to perform activities of daily living.

The included studies were heterogeneous in study design, population, intervention, outcomes reported and length of follow up limiting our ability to synthesize results. The studies addressing pharmacologic treatment did not systematically report harms of treatment, or provide references to publications where harms were described. For foot care, because the studies evaluated multiple types of interventions (e.g., type of therapeutic footwear; surgical procedures) and the number of studies per comparison was limited, we were unable to make conclusions about the risks or benefits of specific interventions and conduct rigorous comparative effectiveness evaluations. Balance training exercises adopted in these studies were diverse ranging from physical therapist guided training to computerized systems, which limited our ability to draw conclusions by intervention type.

### Implications for Clinical and Policy Decisionmaking

Our results have implications for the clinical management of patients with diabetic peripheral neuropathy. The strongest evidence favors a more intensive glycemic control approach for patients with type 2 diabetes, but potential benefits need to be balanced with known harms of intensive treatment, such as hypoglycemia and the potential for increased cardiovascular events and mortality with very intensive control,^95, 96^ a concern identified in other reviews and meta-analyses specifically addressing this topic. Our review confirms existing practice for more intensive approaches to glycemic control in patients with diabetes to prevent complications associated with diabetic peripheral neuropathy, although the target A1c is not clear. Evidence supporting referrals for particular foot care programs, physical therapy modalities, or balance training is limited due to concerns about intermediate measures as outcomes, lower study quality and few studies per intervention.

### Future Research Needs

We identified the need for future research in several areas. Because few studies focused on diabetic peripheral neuropathy in patients with type 1 diabetes, we suggest future research in this unique population.

Regarding interventions, we identified a need for studies to test physical therapy modalities and balance training programs appropriately tailored to the needs of patients with diabetic peripheral neuropathy to prevent falls and improve mobility, function, and quality of life. In addition, future research is needed on low-cost interventions, such as home monitoring of foot skin temperature, as well as health services programs that incorporate a multidisciplinary foot care model for patients with diabetic peripheral neuropathy.

Long-duration studies that assess the effects of glucose lowering medications on a variety of long-term complications of diabetes also need to develop protocols to include diabetic peripheral neuropathy-related complications (ulcers, amputations, and falls). Protocols that systematically assess these patient-important diabetic foot complications, using periodic prospective data collection with foot exams, surveys and medical record review, are needed to capture these outcomes. Even among the few studies that reported on these outcomes, event rates were low, in part due to their lack of systematic ascertainment. Having consistent outcome ascertainment methods across multiple studies would strengthen our ability to combine studies and make accurate estimates of benefits. Nonetheless, although observational studies can provide additional data, cohort studies are still limited due to unobserved confounding factors and selection bias, e.g. why certain patients receive therapy vs. those without intervention. In addition to the collection of data on diabetic peripheral neuropathy related ulcers and amputations, future research needs to evaluate the outcomes of falls and perceived fall risk. Because altered proprioception due to diabetic peripheral neuropathy can also increase risk of falling and fear of falling, these are important clinical and patient-oriented outcomes that should be addressed in future studies.

### Conclusions

We confirmed results from prior reviews in type 2 diabetes that more intensive glycemic control is associated with reduced lower extremity amputations compared with standard glycemic control. However, event rates in the studies were very low. For foot ulcers, we found no effect of intensive glycemic control compared with standard glycemic control. We identified few studies in type 1 diabetes.

For foot care, a previous review found that home monitoring of foot skin temperatures, the use of therapeutic footwear, or integrated foot care may be effective in preventing ulcer incidence or recurrence. Our new search identified only a few new studies and these did not change the conclusions. For falls, neither balance training nor exercise improved outcomes of physical activity or perceived risk of falling. Exercise also did not improve physical activity or perceived risk of falling, and only one study evaluated falls as an outcome.

We recommend that future studies comparing monotherapy and combination pharmacotherapies in patients with type 1 and type 2 diabetes include the complications of diabetic peripheral neuropathy as outcomes, specifically assessing foot ulcers, amputations, falls, and perceived risk of falling. Additional studies evaluating balance, exercise and physical therapy interventions for diabetic peripheral neuropathy are also needed, and should evaluate the patient-relevant outcomes of perceived risk of falling and falls.