# References

1 Centers for Disease Control and Prevention. National Diabetes Statistics Report: Estimates of Diabetes and Its Burden in the United States, 2014. Atlanta, GA: U.S. Department of Health and Human Services; 2014.
2 Griebeler ML, Morey-Vargas OL, Brito JP, . Pharmacologic interventions for painful diabetic neuropathy: An umbrella systematic review and comparative effectiveness network meta-analysis. Ann Intern Med. 2014 Nov 4;161(9):639–49. doi: 10.7326/M14-0511. PMID: 25364885.25364885
3 Feldman EL. Clinical manifestations and diagnosis of diabetic polyneuropathy. Wolters Kluwer; 2015. http://www.uptodate.com/contents/clinical-manifestations-and-diagnosis-of-diabetic-polyneuropathy#H1. Accessed on August 22, 2016.
4 England JD, Gronseth GS, Franklin G, . Distal symmetric polyneuropathy: a definition for clinical research: report of the American Academy of Neurology, the American Association of Electrodiagnostic Medicine, and the American Academy of Physical Medicine and Rehabilitation. Neurology. 2005 Jan 25;64(2):199–207. doi: 10.1212/01.wnl.0000149522.32823.ea. PMID: 15668414.15668414
5 Dyck P, Kratz K, Karnes J, . The prevalence by staged severity of various types of diabetic neuropathy, retinopathy, and nephropathy in a population-based cohort: the Rochester Diabetic Neuropathy Study. Neurology. 1993;43(4):817–24.8469345
6 Tesfaye S, Boulton AJ, Dyck PJ, . Diabetic neuropathies: update on definitions, diagnostic criteria, estimation of severity, and treatments. Diabetes Care. 2010 Oct;33(10):2285–93. doi: 10.2337/dc10-1303. PMID: 20876709.20876709
7 Abbott CA, Malik RA, van Ross ER, . Prevalence and characteristics of painful diabetic neuropathy in a large community-based diabetic population in the U.K. Diabetes Care. 2011 Oct;34(10):2220–4. doi: 10.2337/dc11-1108. PMID: 21852677.21852677
8 CL M, J A, WH H, . Neuropathy among the diabetes control and complications trial cohort 8 years after trial completion. Diabetes Care. 2006;2006(29):340–40.
9 Wiggin TD, Sullivan KA, Pop-Busui R, . Elevated triglycerides correlate with progression of diabetic neuropathy. Diabetes Care. 2009;58(7):1634–40.
10 Wu S, Cao X, He R, . Detrimental impact of hyperlipidemia on the peripheral nervous system: A novel target of medical epidemiological and fundamental research study. Neural Regen Res. 2012 Feb 15;7(5):392–9. doi: 10.3969/j.issn.1673-5374.2012.05.011. PMID: 25774180.25774180
11 Bolen S, Wilson L, Vassy J, . Comparative Effectiveness and Safety of Oral Diabetes Medications for Adults With Type 2 Diabetes. Rockville MD; 2007.
12 Bennett WL, Wilson LM, Bolen S, . Oral Diabetes Medications for Adults With Type 2 Diabetes: An Update. Rockville MD; 2011.
13 Bolen S, Tseng E, Hutfless S, . Diabetes Medications for Adults With Type 2 Diabetes: An Update. Rockville MD; 2016.
14 Shojania KG, Ranji SR, McDonald KM, . Effects of quality improvement strategies for type 2 diabetes on glycemic control: a meta-regression analysis. JAMA. 2006 Jul 26;296(4):427–40. doi: 10.1001/jama.296.4.427. PMID: 16868301.16868301
15 Callaghan BC, Little AA, Feldman EL, . Enhanced glucose control for preventing and treating diabetic neuropathy. Cochrane Database Syst Rev. 2012;6:CD007543. 10.1002/14651858.CD007543.pub2. PMID: 22696371.22696371
16 Streckmann F, Zopf EM, Lehmann HC, . Exercise intervention studies in patients with peripheral neuropathy: a systematic review. Sports Med. 2014 Sep;44(9):1289–304. doi: 10.1007/s40279-014-0207-5. PMID: 24927670.24927670
17 Hijmans JM, Geertzen JH, Dijkstra PU, . A systematic review of the effects of shoes and other ankle or foot appliances on balance in older people and people with peripheral nervous system disorders. Gait Posture. 2007 Feb;25(2):316–23. doi: 10.1016/j.gaitpost.2006.03.010. PMID: 16687248.16687248
18 van Netten JJ, Price PE, Lavery LA, . Prevention of foot ulcers in the at-risk patient with diabetes: a systematic review. Diabetes Metab Res Rev. 2015 Sep 5 10.1002/dmrr.2701. PMID: 26340966.26340966
19 National Institute for Health and Care Excellence. Neuropathic pain: the pharmacological management of neuropathic pain in adults in non-specialist settings. UK: NICE;. 2013.
20 Chaudhry V, Russell J, Belzberg A. Decompressive surgery of lower limbs for symmetrical diabetic peripheral neuropathy. Cochrane Database Syst Rev. 2008(3):CD006152. 10.1002/14651858.CD006152.pub2. PMID: 18646138.18646138
21 Derry S, Wiffen PJ, Aldington D, . Nortriptyline for neuropathic pain in adults. Cochrane Database Syst Rev. 2015;1:CD011209. PMID: 25569864.25569864
22 Finnerup NB, Attal N, Haroutounian S, . Pharmacotherapy for neuropathic pain in adults: a systematic review and meta-analysis. Lancet Neurol. 2015 Feb;14(2):162–73. doi: 10.1016/S1474-4422(14)70251-0. PMID: 25575710.25575710
23 Lunn MP, Hughes RA, Wiffen PJ. Duloxetine for treating painful neuropathy, chronic pain or fibromyalgia. Cochrane Database Syst Rev. 2014;1:CD007115. 10.1002/14651858.CD007115.pub3. PMID: 24385423.24385423
24 Moore RA, Straube S, Wiffen PJ, . Pregabalin for acute and chronic pain in adults. Cochrane Database Syst Rev. 2009(3):CD007076. 10.1002/14651858.CD007076.pub2. PMID: 19588419.19588419
25 Snedecor SJ, Sudharshan L, Cappelleri JC, . Systematic review and meta-analysis of pharmacological therapies for painful diabetic peripheral neuropathy. Pain Pract. 2014 Feb;14(2):167–84. doi: 10.1111/papr.12054. PMID: 23534696.23534696
26 Methods Guide for Effectiveness and Comparative Effectiveness Reviews. AHRQ Publication No. 10(14)-EHC063-EF. Agency for Healthcare Research and Quality. Rockville, MD. January 2014. Rockville, MD: 2014. www.effectivehealthcare.ahrq.gov
27 Whiting P, Savovic J, Higgins JP, . ROBIS: A new tool to assess risk of bias in systematic reviews was developed. J Clin Epidemiol. 2015 Jun 16 10.1016/j.jclinepi.2015.06.005. PMID: 26092286.26092286
28 GSe HJ. Cochrane handbook for systemic reviews of interventions Version 5.1.0. The Cochrane Collaboration. 2011;Oxford, England. http://handbook.cochrane.org..
29 Sterne JAC, Higgins JPT, NRSI RBobotdgfA-. A Cochrane Risk Of Bias Assessment Tool: for Non-Randomized Studies of Interventions (ACROBATNRSI), Version 1.0.0, 24 September 2014. http://www.riskofbias.info 2014.
30 Fu R, Vandermeer, BW Shamliyan TA, . Methods Guide for Effectiveness and Comparative Effectiveness Reviews: Handling Continuous Outcomes in Quantitative Synthesis Rockville MD: Agency for Healthcare Research and Quality (US); 2008.
31 Martin CL, Albers J, Herman WH, . Neuropathy among the diabetes control and complications trial cohort 8 years after trial completion. Diabetes Care. 2006 Feb;29(2):340–4. PMID: 16443884.16443884
32 Reichard P, Nilsson BY, U. R. The effect of long-term intensified insulin treatment on the development of microvascular complications of diabetes mellitus. N Engl J Med. 1993;329(5):304–9.8147960
33 Rathsman B, Jensen-Urstad K, Nystrom T. Intensified insulin treatment is associated with improvement in skin microcirculation and ischaemic foot ulcer in patients with type 1 diabetes mellitus: a long-term follow-up study. Diabetologia. 2014 Aug;57(8):1703–10. doi: 10.1007/s00125-014-3248-2. PMID: 24802206.24802206
34 Effect of intensive blood-glucose control with metformin on complications in overweight patients with type 2 diabetes (UKPDS 34). UK Prospective Diabetes Study (UKPDS) Group. Lancet. 1998 Sep 12;352(9131):854–65. PMID: 9742977.9742977
35 Gaede P, Vedel P, Larsen N, . Multifactorial intervention and cardiovascular disease in patients with type 2 diabetes. N Engl J Med. 2003 Jan 30;348(5):383–93. doi: 10.1056/NEJMoa021778. PMID: 12556541.12556541
36 Gaede P, Lund-Andersen H, Parving HH, . Effect of a multifactorial intervention on mortality in type 2 diabetes. N Engl J Med. 2008 Feb 7;358(6):580–91. doi: 10.1056/NEJMoa0706245. PMID: 18256393.18256393
37 Jaiswal M, Martin CL, Brown MB, . Effects of exenatide on measures of diabetic neuropathy in subjects with type 2 diabetes: results from an 18-month proof-of-concept open-label randomized study. J Diabetes Complications. 2015 Jul 17 10.1016/j.jdiacomp.2015.07.013. PMID: 26264399.26264399
38 Kostev K, Dippel FW, Rockel T, . Risk of diabetic foot ulceration during treatment with insulin glargine and NPH insulin. J Wound Care. 2012 Oct;21(10):483–4, 6–9. doi: 10.12968/jowc.2012.21.10.483. PMID: 23103482.23103482
39 Dormandy JA, Charbonnel B, Eckland DJ, . Secondary prevention of macrovascular events in patients with type 2 diabetes in the PROactive Study (PROspective pioglitAzone Clinical Trial In macroVascular Events): a randomised controlled trial. Lancet. 2005 Oct 8;366(9493):1279–89. doi: 10.1016/S0140-6736(05)67528-9. PMID: 16214598.16214598
40 Duckworth W, Abraira C, Moritz T, . Glucose control and vascular complications in veterans with type 2 diabetes. N Engl J Med. 2009 Jan 8;360(2):129–39. doi: 10.1056/NEJMoa0808431. PMID: 19092145.19092145
41 Abraira C, Colwell J, Nuttall F, . Cardiovascular events and correlates in the Veterans Affairs Diabetes Feasibility Trial. Veterans Affairs Cooperative Study on Glycemic Control and Complications in Type II Diabetes. Arch Intern Med. 1997;157(2):181–8.9009975
42 Abraira C, Colwell JA, Nuttall FQ, . Veterans Affairs Cooperative Study on glycemic control and complications in type II diabetes (VA CSDM). Results of the feasibility trial. Veterans Affairs Cooperative Study in Type II Diabetes. Diabetes Care. 1995 Aug;18(8):1113–23. PMID: 7587846.7587846
43 Araki A, Iimuro S, Sakurai T, . apanese Elderly Diabetes Intervention Trial Study Group. Long-term multiple risk factor interventions in Japanese elderly diabetic patients: the Japanese Elderly Diabetes Intervention Trial--study design, baseline characteristics and effects of intervention. Geriatr Gerontol Int. 2012;Suppl 1:7–17.22435936
44 Simmons RK, Sharp SJ, Sandbæk A, . Does early intensive multifactorial treatment reduce total cardiovascular burden in individuals with screen-detected diabetes? Findings from the ADDITION-Europe cluster-randomized trial. Diabet Med. 2012;29(11):e409–16.22823477
45 Knatterud GL, Klimt CR, Levin ME, . Effects of hypoglycemic agents on vascular complications in patients with adult-onset diabetes. VII. Mortality and selected nonfatal events with insulin treatment. JAMA. 1978;240(1):37–42.351218
46 The effect of intensive treatment of diabetes on the development and progression of long-term complications in insulin-dependent diabetes mellitus. The Diabetes Control and Complications Trial Research Group. N Engl J Med. 1993 Sep 30;329(14):977–86. doi: 10.1056/NEJM199309303291401. PMID: 8366922.8366922
47 Intensive blood-glucose control with sulphonylureas or insulin compared with conventional treatment and risk of complications in patients with type 2 diabetes (UKPDS 33). UK Prospective Diabetes Study (UKPDS) Group. Lancet. 1998 Sep 12;352(9131):837–53. PMID: 9742976.9742976
48 Skafjeld A, Iversen MM, Holme I, . A pilot study testing the feasibility of skin temperature monitoring to reduce recurrent foot ulcers in patients with diabetes - a randomized controlled trial. BMC Endocr Disord. 2015;15(1):55. doi: 10.1186/s12902-015-0054-x. PMID: 26452544.26452544
49 Monami M, Zannoni S, Gaias M, . Effects of a Short Educational Program for the Prevention of Foot Ulcers in High-Risk Patients: A Randomized Controlled Trial. Int J Endocrinol. 2015;2015:615680. doi: 10.1155/2015/615680. PMID: 26448748.26448748
50 Shah BR, Hwee J, Cauch-Dudek K, . Diabetes self-management education is not associated with a reduction in long-term diabetes complications: An effectiveness study in an elderly population. J Eval Clin Pract. 2015;21(4):656–61.25847059
51 Gibson TB, Driver VR, Wrobel JS, . Podiatrist care and outcomes for patients with diabetes and foot ulcer. Int Wound J. 2014 Dec;11(6):641–8. doi: 10.1111/iwj.12021. PMID: 23374540.23374540
52 Chin YF, Liang J, Wang WS, . The role of foot self-care behavior on developing foot ulcers in diabetic patients with peripheral neuropathy: a prospective study. Int J Nurs Stud. 2014 Dec;51(12):1568–74. doi: 10.1016/j.ijnurstu.2014.05.001. PMID: 24866324.24866324
53 Liang R, Dai X, Zuojie L, . Two-Year Foot Care Program for Minority Patients with Type 2 Diabetes Mellitus of Zhuang Tribe in Guangxi, China. Canadian Journal of Diabetes 2012;36:15–8.
54 Cisneros LL. [Evaluation of a neuropathic ulcers prevention program for patients with diabetes]. Rev Bras Fisioter. 2010 Jan–Feb;14(1):31–7. PMID: 20414559.20414559
55 Plank J, Haas W, Rakovac I, . Evaluation of the impact of chiropodist care in the secondary prevention of foot ulcerations in diabetic subjects. Diabetes Care. 2003 Jun;26(6):1691–5. PMID: 12766095.12766095
56 Dargis V, Pantelejeva O, Jonushaite A, . Benefits of a multidisciplinary approach in the management of recurrent diabetic foot ulceration in Lithuania: A prospective study. Diabetes Care. 1999;22(9):1428–31.10480504
57 Lavery L, LaFontaine J, Higgins KR, . Shear-reducing insoles to prevent foot ulceration in high-risk diabetic patients. Adv Skin Wound Care. 2012 Nov;25(11):519–24; quiz 25–6. doi: 10.1097/01.asw.0000422625.17407.93. PMID: 23080240.23080240
58 Armstrong DG, Holtz-Neiderer K, Wendel C, . Skin temperature monitoring reduces the risk for diabetic foot ulceration in high-risk patients. Am J Med. 2007 Dec;120(12):1042–6. doi: 10.1016/j.amjmed.2007.06.028. PMID: 18060924.18060924
59 Lavery LA, Higgins KR, Lanctot DR, . Home monitoring of foot skin temperatures to prevent ulceration. Diabetes Care. 2004 Nov;27(11):2642–7. PMID: 15504999.15504999
60 Lavery LA, Higgins KR, Lanctot DR, . Preventing diabetic foot ulcer recurrence in high-risk patients: use of temperature monitoring as a self-assessment tool. Diabetes Care. 2007;30(1):14–20.17192326
61 Armstrong DG, Holtz K, Wu S. Can the use of a topical antifungal nail lacquer reduce risk for diabetic foot ulceration? Results from a randomised controlled pilot study. Int Wound J. 2005 Jun;2(2):166–70. doi: 10.1111/j.1742-4801.2005.00097.x. PMID: 16722866.16722866
62 Gershater M, Pilhammar E, Apelqvist J, . Patient education for the prevention of diabetic foot ulcers: Interim analysis of a randomised controlled trial due to morbidity and mortality of participants. European Diabetes Nursing. 2011;8:102–7b.
63 Lincoln NB, Radford KA, Game FL, . Education for secondary prevention of foot ulcers in people with diabetes: a randomised controlled trial. Diabetologia. 2008 Nov;51(11):1954–61. doi: 10.1007/s00125-008-1110-0. PMID: 18758747.18758747
64 Scire V, Leporati E, Teobaldi I, . Effectiveness and safety of using Podikon digital silicone padding in the primary prevention of neuropathic lesions in the forefoot of diabetic patients. J Am Podiatr Med Assoc. 2009 Jan–Feb;99(1):28–34. PMID: 19141719.19141719
65 Rizzo L, Tedeschi A, Fallani E, . Custom-made orthesis and shoes in a structured follow-up program reduces the incidence of neuropathic ulcers in high-risk diabetic foot patients. Int J Low Extrem Wounds. 2012 Mar;11(1):59–64. doi: 10.1177/1534734612438729. PMID: 22336901.22336901
66 Ulbrecht JS, Hurley T, Mauger DT, . Prevention of recurrent foot ulcers with plantar pressure-based in-shoe orthoses: the CareFUL prevention multicenter randomized controlled trial. Diabetes Care. 2014 Jul;37(7):1982–9. doi: 10.2337/dc13-2956. PMID: 24760263.24760263
67 Uccioli L, Faglia E, Monticone G, . Manufactured shoes in the prevention of diabetic foot ulcers. Diabetes Care. 1995 Oct;18(10):1376–8. PMID: 8721941.8721941
68 Viswanathan V, Madhavan S, Gnanasundaram S, . Effectiveness of different types of footwear insoles for the diabetic neuropathic foot: a follow-up study. Diabetes Care. 2004 Feb;27(2):474–7. PMID: 14747231.14747231
69 Busch K, Chantelau E. Effectiveness of a new brand of stock ‘diabetic’ shoes to protect against diabetic foot ulcer relapse. A prospective cohort study. Diabet Med. 2003 Aug;20(8):665–9. PMID: 12873296.12873296
70 Reike H, Bruning A, Rischbieter E, . Recurrence of foot lesions in patients with diabetic foot syndrome: Influence of custom-molded orthotic device. Diabetes und Stoffwechsel. 1997;6:107–13.
71 Armstrong DG, Fiorito JL, Leykum BJ, . Clinical efficacy of the pan metatarsal head resection as a curative procedure in patients with diabetes mellitus and neuropathic forefoot wounds. Foot Ankle Spec. 2012 Aug;5(4):235–40. doi: 10.1177/1938640012449038. PMID: 22715496.22715496
72 Vanlerberghe B, Devemy F, Duhamel A, . [Conservative surgical treatment for diabetic foot ulcers under the metatarsal heads. A retrospective case-control study]. Ann Chir Plast Esthet. 2014 Jun;59(3):161–9. doi: 10.1016/j.anplas.2013.07.008. PMID: 23973116.23973116
73 Mueller MJ, Sinacore DR, Hastings MK, . Impact of achilles tendon lengthening on functional limitations and perceived disability in people with a neuropathic plantar ulcer. Diabetes Care. 2004 Jul;27(7):1559–64. PMID: 15220228.15220228
74 Bunner AE, Wells CL, Gonzales J, . A dietary intervention for chronic diabetic neuropathy pain: a randomized controlled pilot study. Nutr Diabetes. 2015;5:e158. doi: 10.1038/nutd.2015.8. PMID: 26011582.26011582
75 Grewal GS, Schwenk M, Lee-Eng J, . Sensor-Based Interactive Balance Training with Visual Joint Movement Feedback for Improving Postural Stability in Diabetics with Peripheral Neuropathy: A Randomized Controlled Trial. Gerontology. 2015 Feb 19 10.1159/000371846. PMID: 25721132.25721132
76 Lee K, Lee S, Song C. Whole-body vibration training improves balance, muscle strength and glycosylated hemoglobin in elderly patients with diabetic neuropathy. Tohoku J Exp Med. 2013;231(4):305–14. PMID: 24334483.24334483
77 Song CH, Petrofsky JS, Lee SW, . Effects of an exercise program on balance and trunk proprioception in older adults with diabetic neuropathies. Diabetes Technol Ther. 2011 Aug;13(8):803–11. doi: 10.1089/dia.2011.0036. PMID: 21561371.21561371
78 Eftekhar-Sadat B, Azizi R, Aliasgharzadeh A, . Effect of balance training with Biodex Stability System on balance in diabetic neuropathy. Ther Adv Endocrinol Metab. 2015 Oct;6(5):233–40. doi: 10.1177/2042018815595566. PMID: 26445646.26445646
79 Kruse RL, Lemaster JW, Madsen RW. Fall and balance outcomes after an intervention to promote leg strength, balance, and walking in people with diabetic peripheral neuropathy: “feet first” randomized controlled trial. Phys Ther. 2010 Nov;90(11):1568–79. doi: 10.2522/ptj.20090362. PMID: 20798179.20798179
80 Lemaster JW, Mueller MJ, Reiber GE, . Effect of weight-bearing activity on foot ulcer incidence in people with diabetic peripheral neuropathy: feet first randomized controlled trial. Phys Ther. 2008 Nov;88(11):1385–98. doi: 10.2522/ptj.20080019. PMID: 18801859.18801859
81 Richardson JK, Sandman D, Vela S. A focused exercise regimen improves clinical measures of balance in patients with peripheral neuropathy. Arch Phys Med Rehabil. 2001 Feb;82(2):205–9. doi: 10.1053/apmr.2001.19742. PMID: 11239311.11239311
82 Kordi Yoosefinejad A, Shadmehr A, Olyaei G, . Short-term effects of the whole-body vibration on the balance and muscle strength of type 2 diabetic patients with peripheral neuropathy: a quasi-randomized-controlled trial study. J Diabetes Metab Disord. 2015;14:45. doi: 10.1186/s40200-015-0173-y. PMID: 26052508.26052508
83 Taveggia G, Villafane JH, Vavassori F, . Multimodal treatment of distal sensorimotor polyneuropathy in diabetic patients: a randomized clinical trial. J Manipulative Physiol Ther. 2014 May;37(4):242–52. doi: 10.1016/j.jmpt.2013.09.007. PMID: 24656867.24656867
84 Sartor CD, Hasue RH, Cacciari LP, . Effects of strengthening, stretching and functional training on foot function in patients with diabetic neuropathy: results of a randomized controlled trial. BMC Musculoskelet Disord. 2014;15:137. doi: 10.1186/1471-2474-15-137. PMID: 24767584.24767584
85 Dixit S, Maiya A, Shastry B. Effect of aerobic exercise on quality of life in population with diabetic peripheral neuropathy in type 2 diabetes: a single blind, randomized controlled trial. Qual Life Res. 2014 Jun;23(5):1629–40. doi: 10.1007/s11136-013-0602-7. PMID: 24326731.24326731
86 Lemaster JW, Reiber GE, Smith DG, . Daily weight-bearing activity does not increase the risk of diabetic foot ulcers. Med Sci Sports Exerc. 2003 Jul;35(7):1093–9. doi: 10.1249/01.mss.0000074459.41029.75. PMID: 12840628.12840628
87 Mueller MJ, Tuttle LJ, Lemaster JW, . Weight-bearing versus nonweight-bearing exercise for persons with diabetes and peripheral neuropathy: a randomized controlled trial. Arch Phys Med Rehabil. 2013 May;94(5):829–38. doi: 10.1016/j.apmr.2012.12.015. PMID: 23276801.23276801
88 Chatchawan U, Eungpinichpong W, Plandee P, . Effects of thai foot massage on balance performance in diabetic patients with peripheral neuropathy: a randomized parallel-controlled trial. Med Sci Monit Basic Res. 2015;21:68–75. doi: 10.12659/msmbr.894163. PMID: 25892354.25892354
89 Kahler P, Grevstad B, Almdal T, . Targeting intensive versus conventional glycaemic control for type 1 diabetes mellitus: a systematic review with meta-analyses and trial sequential analyses of randomised clinical trials. BMJ Open. 2014;4(8):e004806. doi: 10.1136/bmjopen-2014-004806. PMID: 25138801.25138801
90 Hemmingsen B, Lund SS, Gluud C, . Targeting intensive glycaemic control versus targeting conventional glycaemic control for type 2 diabetes mellitus. Cochrane Database Syst Rev. 2013;11:CD008143. 10.1002/14651858.CD008143.pub3. PMID: 24214280.24214280
91 Hasan R, Firwana B, Elraiyah T, . A systematic review and meta-analysis of glycemic control for the prevention of diabetic foot syndrome. J Vasc Surg. 2016 Feb;63(2 Suppl):22S–8S e2. doi: 10.1016/j.jvs.2015.10.005. PMID: 26804364.26804364
92 Hingorani A, LaMuraglia GM, Henke P, . The management of diabetic foot: A clinical practice guideline by the Society for Vascular Surgery in collaboration with the American Podiatric Medical Association and the Society for Vascular Medicine. J Vasc Surg. 2016 Feb;63(2 Suppl):3S–21S. doi: 10.1016/j.jvs.2015.10.003. PMID: 26804367.26804367
93 Group AS, Gerstein HC, Miller ME, . Long-term effects of intensive glucose lowering on cardiovascular outcomes. N Engl J Med. 2011 Mar 3;364(9):818–28. doi: 10.1056/NEJMoa1006524. PMID: 21366473.21366473
94 Litzelman DK, Slemenda CW, Langefeld CD, . Reduction of lower extremity clinical abnormalities in patients with non-insulin-dependent diabetes mellitus. A randomized, controlled trial. Ann Intern Med. 1993 Jul 1;119(1):36–41. PMID: 8498761.8498761
95 Hemmingsen B, Lund SS, Gluud C, . Targeting intensive glycaemic control versus targeting conventional glycaemic control for type 2 diabetes mellitus. Cochrane Database Syst Rev. 2013(11):CD008143. 10.1002/14651858.CD008143.pub3. PMID: 24214280.24214280
96 Boussageon R, Bejan-Angoulvant T, Saadatian-Elahi M, . Effect of intensive glucose lowering treatment on all cause mortality, cardiovascular death, and microvascular events in type 2 diabetes: meta-analysis of randomised controlled trials. BMJ. 2011;343:d4169. doi: 10.1136/bmj.d4169. PMID: 21791495.21791495
97 Rauck R, Makumi CW, Schwartz S, . A randomized, controlled trial of gabapentin enacarbil in subjects with neuropathic pain associated with diabetic peripheral neuropathy. Pain Pract. 2013 Jul;13(6):485–96. doi: 10.1111/papr.12014. PMID: 23186035.23186035
98 Tesfaye S, Wilhelm S, Lledo A, . Duloxetine and pregabalin: high-dose monotherapy or their combination? The “COMBO-DN study”--a multinational, randomized, double-blind, parallel-group study in patients with diabetic peripheral neuropathic pain. Pain. 2013 Dec;154(12):2616–25. doi: 10.1016/j.pain.2013.05.043. PMID: 23732189.23732189
99 Karmakar S, Rashidian H, Chan C, . Investigating the role of neuropathic pain relief in decreasing gait variability in diabetes mellitus patients with neuropathic pain: a randomized, double-blind crossover trial. J Neuroeng Rehabil. 2014;11:125. doi: 10.1186/1743-0003-11-125. PMID: 25139539.25139539
100 Sandercock D, Cramer M, Biton V, . A gastroretentive gabapentin formulation for the treatment of painful diabetic peripheral neuropathy: efficacy and tolerability in a double-blind, randomized, controlled clinical trial. Diabetes Res Clin Pract. 2012 Sep;97(3):438–45. doi: 10.1016/j.diabres.2012.03.010. PMID: 22497967.22497967
101 Freeman R, McIntosh KA, Vijapurkar U, . Topiramate and physiologic measures of nerve function in polyneuropathy. Acta Neurol Scand. 2007 Apr;115(4):222–31. doi: 10.1111/j.1600-0404.2006.00789.x. PMID: 17376119.17376119
102 Atli A, Dogra S. Zonisamide in the treatment of painful diabetic neuropathy: a randomized, double-blind, placebo-controlled pilot study. Pain Med. 2005 May–Jun;6(3):225–34. 10.1111/j.1526-4637.2005.05035.x. PMID: 15972086.15972086
103 Gao Y, Guo X, Han P, . Treatment of patients with diabetic peripheral neuropathic pain in China: a double-blind randomised trial of duloxetine vs. placebo. Int J Clin Pract. 2015 Sep;69(9):957–66. doi: 10.1111/ijcp.12641. PMID: 25939897.25939897
104 Rowbotham MC, Arslanian A, Nothaft W, . Efficacy and safety of the alpha4beta2 neuronal nicotinic receptor agonist ABT-894 in patients with diabetic peripheral neuropathic pain. Pain. 2012 Apr;153(4):862–8. doi: 10.1016/j.pain.2012.01.009. PMID: 22386472.22386472
105 Allen R, Sharma U, Barlas S. Clinical experience with desvenlafaxine in treatment of pain associated with diabetic peripheral neuropathy. J Pain Res. 2014;7:339–51. doi: 10.2147/jpr.s55682. PMID: 25018648.25018648
106 Hanna M, O’Brien C, Wilson MC. Prolonged-release oxycodone enhances the effects of existing gabapentin therapy in painful diabetic neuropathy patients. Eur J Pain. 2008 Aug;12(6):804–13. doi: 10.1016/j.ejpain.2007.12.010. PMID: 18262450.18262450
107 Niesters M, Proto PL, Aarts L, . Tapentadol potentiates descending pain inhibition in chronic pain patients with diabetic polyneuropathy. Br J Anaesth. 2014 Jul;113(1):148–56. doi: 10.1093/bja/aeu056. PMID: 24713310.24713310
108 Vinik AI, Shapiro DY, Rauschkolb C, . A randomized withdrawal, placebo-controlled study evaluating the efficacy and tolerability of tapentadol extended release in patients with chronic painful diabetic peripheral neuropathy. Diabetes Care. 2014 Aug;37(8):2302–9. doi: 10.2337/dc13-2291. PMID: 24848284.24848284
109 Harati Y, Gooch C, Swenson M, . Double-blind randomized trial of tramadol for the treatment of the pain of diabetic neuropathy. Neurology. 1998 Jun;50(6):1842–6. PMID: 9633738.9633738
110 Kulkantrakorn K, Lorsuwansiri C, Meesawatsom P. 0.025% capsaicin gel for the treatment of painful diabetic neuropathy: a randomized, double-blind, crossover, placebo-controlled trial. Pain Pract. 2013 Jul;13(6):497–503. doi: 10.1111/papr.12013. PMID: 23228119.23228119
111 Chad DA, Aronin N, Lundstrom R, . Does capsaicin relieve the pain of diabetic neuropathy? Pain. 1990 Sep;42(3):387–8. PMID: 1701234.1701234
112 Campbell CM, Kipnes MS, Stouch BC, . Randomized control trial of topical clonidine for treatment of painful diabetic neuropathy. Pain. 2012 Sep;153(9):1815–23. doi: 10.1016/j.pain.2012.04.014. PMID: 22683276.22683276
113 Shaibani AI, Pope LE, Thisted R, . Efficacy and safety of dextromethorphan/quinidine at two dosage levels for diabetic neuropathic pain: a double-blind, placebo-controlled, multicenter study. Pain Med. 2012 Feb;13(2):243–54. doi: 10.1111/j.1526-4637.2011.01316.x. PMID: 22314263.22314263
114 Toth C, Mawani S, Brady S, . An enriched-enrolment, randomized withdrawal, flexible-dose, double-blind, placebo-controlled, parallel assignment efficacy study of nabilone as adjuvant in the treatment of diabetic peripheral neuropathic pain. Pain. 2012 Oct;153(10):2073–82. doi: 10.1016/j.pain.2012.06.024. PMID: 22921260.22921260
115 Yuan RY, Sheu JJ, Yu JM, . Botulinum toxin for diabetic neuropathic pain: a randomized double-blind crossover trial. Neurology. 2009 Apr 28;72(17):1473–8. doi: 10.1212/01.wnl.0000345968.05959.cf. PMID: 19246421.19246421
116 Ghasemi M, Ansari M, Basiri K, . The effects of intradermal botulinum toxin type a injections on pain symptoms of patients with diabetic neuropathy. J Res Med Sci. 2014 Feb;19(2):106–11. PMID: 24778662.24778662
117 Kvinesdal B, Molin J, Froland A, . Imipramine treatment of painful diabetic neuropathy. JAMA. 1984 Apr 6;251(13):1727–30. PMID: 6366276.6366276
118 Sindrup SH, Gram LF, Brosen K, . The selective serotonin reuptake inhibitor paroxetine is effective in the treatment of diabetic neuropathy symptoms. Pain. 1990 Aug;42(2):135–44. PMID: 2147235.2147235
119 Wright JM, Oki JC, Graves L, 3rd. Mexiletine in the symptomatic treatment of diabetic peripheral neuropathy. Ann Pharmacother. 1997 Jan;31(1):29–34. PMID: 8997461.8997461
120 McCleane G. 200 mg daily of lamotrigine has no analgesic effect in neuropathic pain: a randomised, double-blind, placebo controlled trial. Pain. 1999 Oct;83(1):105–7. PMID: 10506679.10506679
121 Satoh J, Yagihashi S, Baba M, . Efficacy and safety of pregabalin for treating neuropathic pain associated with diabetic peripheral neuropathy: a 14 week, randomized, double-blind, placebo-controlled trial. Diabet Med. 2011 Jan;28(1):109–16. doi: 10.1111/j.1464-5491.2010.03152.x. PMID: 21166852.21166852
122 Wilton T. Tegretol in the Treatment of Diabetic Neuropathy. SA Mediese Tydskrif. 1974:869–72.
123 Dejgard A, Petersen P, Kastrup J. Mexiletine for treatment of chronic painful diabetic neuropathy. Lancet. 1988 Jan 2–9;1(8575–6):9–11. PMID: 2891940.2891940
124 Lesser H, Sharma U, LaMoreaux L, . Pregabalin relieves symptoms of painful diabetic neuropathy: a randomized controlled trial. Neurology. 2004 Dec 14;63(11):2104–10. PMID: 15596757.15596757
125 Rosenstock J, Tuchman M, LaMoreaux L, . Pregabalin for the treatment of painful diabetic peripheral neuropathy: a double-blind, placebo-controlled trial. Pain. 2004 Aug;110(3):628–38. doi: 10.1016/j.pain.2004.05.001. PMID: 15288403.15288403
126 Tolle T, Freynhagen R, Versavel M, . Pregabalin for relief of neuropathic pain associated with diabetic neuropathy: a randomized, double-blind study. Eur J Pain. 2008 Feb;12(2):203–13. doi: 10.1016/j.ejpain.2007.05.003. PMID: 17631400.17631400
127 Richter RW, Portenoy R, Sharma U, . Relief of painful diabetic peripheral neuropathy with pregabalin: a randomized, placebo-controlled trial. J Pain. 2005 Apr;6(4):253–60. doi: 10.1016/j.jpain.2004.12.007. PMID: 15820913.15820913
128 Ziegler D, Duan WR, An G, . A randomized double-blind, placebo-, and active-controlled study of T-type calcium channel blocker ABT-639 in patients with diabetic peripheral neuropathic pain. Pain. 2015 Oct;156(10):2013–20. doi: 10.1097/j.pain.0000000000000263. PMID: 26067585.26067585
129 Simpson DA. Gabapentin and venlafaxine for the treatment of painful diabetic neuropathy. J Clin Neuromuscul Dis. 2001 Dec;3(2):53–62. PMID: 19078655.19078655
130 Backonja M, Beydoun A, Edwards KR, . Gabapentin for the symptomatic treatment of painful neuropathy in patients with diabetes mellitus: a randomized controlled trial. JAMA. 1998 Dec 2;280(21):1831–6. PMID: 9846777.9846777
131 Dogra S, Beydoun S, Mazzola J, . Oxcarbazepine in painful diabetic neuropathy: a randomized, placebo-controlled study. Eur J Pain. 2005 Oct;9(5):543–54. doi: 10.1016/j.ejpain.2004.11.006. PMID: 16139183.16139183
132 Grosskopf J, Mazzola J, Wan Y, . A randomized, placebo-controlled study of oxcarbazepine in painful diabetic neuropathy. Acta Neurol Scand. 2006 Sep;114(3):177–80. doi: 10.1111/j.1600–0404.2005.00559.x. PMID: 16911345.16911345
133 Beydoun A, Shaibani A, Hopwood M, . Oxcarbazepine in painful diabetic neuropathy: results of a dose-ranging study. Acta Neurol Scand. 2006 Jun;113(6):395–404. doi: 10.1111/j.1600-0404.2006.00631.x. PMID: 16674606.16674606
134 Raskin P, Donofrio PD, Rosenthal NR, . Topiramate vs placebo in painful diabetic neuropathy: analgesic and metabolic effects. Neurology. 2004 Sep 14;63(5):865–73. PMID: 15365138.15365138
135 Rauck RL, Shaibani A, Biton V, . Lacosamide in painful diabetic peripheral neuropathy: a phase 2 double-blind placebo-controlled study. Clin J Pain. 2007 Feb;23(2):150–8. doi: 10.1097/01.ajp.0000210957.39621.b2. PMID: 17237664.17237664
136 Wernicke JF, Pritchett YL, D’Souza DN, . A randomized controlled trial of duloxetine in diabetic peripheral neuropathic pain. Neurology. 2006 Oct 24;67(8):1411–20. doi: 10.1212/01.wnl.0000240225.04000.1a. PMID: 17060567.17060567
137 Gao Y, Ning G, Jia WP, . Duloxetine versus placebo in the treatment of patients with diabetic neuropathic pain in China. Chin Med J (Engl). 2010 Nov;123(22):3184–92. PMID: 21163113.21163113
138 Goldstein DJ, Lu Y, Detke MJ, . Duloxetine vs. placebo in patients with painful diabetic neuropathy. Pain. 2005 Jul;116 1–2:109–18. doi: 10.1016/j.pain.2005.03.029. PMID: 15927394.15927394
139 Gimbel JS, Richards P, Portenoy RK. Controlled-release oxycodone for pain in diabetic neuropathy: a randomized controlled trial. Neurology. 2003 Mar 25;60(6):927–34. PMID: 12654955.12654955
140 Freeman R, Raskin P, Hewitt DJ, . Randomized study of tramadol/acetaminophen versus placebo in painful diabetic peripheral neuropathy. Curr Med Res Opin. 2007 Jan;23(1):147–61. doi: 10.1185/030079906x162674. PMID: 17257476.17257476
141 Schwartz S, Etropolski MS, Shapiro DY, . A pooled analysis evaluating the efficacy and tolerability of tapentadol extended release for chronic, painful diabetic peripheral neuropathy. Clin Drug Investig. 2015 Feb;35(2):95–108. doi: 10.1007/s40261-014-0249-3. PMID: 25503082.25503082
142 Sang CN, Booher S, Gilron I, . Dextromethorphan and memantine in painful diabetic neuropathy and postherpetic neuralgia: efficacy and dose-response trials. Anesthesiology. 2002 May;96(5):1053–61. PMID: 11981142.11981142
143 Boyle J, Eriksson ME, Gribble L, . Randomized, placebo-controlled comparison of amitriptyline, duloxetine, and pregabalin in patients with chronic diabetic peripheral neuropathic pain: impact on pain, polysomnographic sleep, daytime functioning, and quality of life. Diabetes Care. 2012 Dec;35(12):2451–8. doi: 10.2337/dc12-0656. PMID: 22991449.22991449
144 Ziegler D, Low PA, Litchy WJ, . Efficacy and safety of antioxidant treatment with alpha-lipoic acid over 4 years in diabetic polyneuropathy: the NATHAN 1 trial. Diabetes Care. 2011 Sep;34(9):2054–60. doi: 10.2337/dc11-0503. PMID: 21775755.21775755
145 Ziegler D, Ametov A, Barinov A, . Oral treatment with alpha-lipoic acid improves symptomatic diabetic polyneuropathy: the SYDNEY 2 trial. Diabetes Care. 2006 Nov;29(11):2365–70. doi: 10.2337/dc06-1216. PMID: 17065669.17065669
146 Ziegler D, Hanefeld M, Ruhnau KJ, . Treatment of symptomatic diabetic polyneuropathy with the antioxidant α-lipoic acid: A 7-month multicenter randomized controlled trial (ALADIN III study). Diabetes Care. 1999;22(8):1296–301.10480774
147 Ziegler D, Hanefeld M, Ruhnau KJ, . Treatment of symptomatic diabetic peripheral neuropathy with alpha- lipoic acid. A 3-week multicentre randomized controlled trial (ALADIN Study. Diabetes Und Stoffwechsel. 1996;5(3 suppl.):102–10.
148 Ametov AS, Barinov A, Dyck PJ, . The sensory symptoms of diabetic polyneuropathy are improved with alpha-lipoic acid: the SYDNEY trial. Diabetes Care. 2003 Mar;26(3):770–6. PMID: 12610036.12610036
149 Ruhnau KJ, Meissner HP, Finn JR, . Effects of 3-week oral treatment with the antioxidant thioctic acid (alpha-lipoic acid) in symptomatic diabetic polyneuropathy. Diabet Med. 1999 Dec;16(12):1040–3. PMID: 10656234.10656234
150 De Grandis D, Minardi C. Acetyl-L-carnitine (levacecarnine) in the treatment of diabetic neuropathy. A long-term, randomised, double-blind, placebo-controlled study. Drugs R D. 2002;3(4):223–31. PMID: 12455197.12455197
151 Garrow AP, Xing M, Vere J, . Role of acupuncture in the management of diabetic painful neuropathy (DPN): a pilot RCT. Acupunct Med. 2014 Jun;32(3):242–9. doi: 10.1136/acupmed-2013-010495. PMID: 24657491.24657491
152 Otis JD, Sanderson K, Hardway C, . A randomized controlled pilot study of a cognitive-behavioral therapy approach for painful diabetic peripheral neuropathy. J Pain. 2013 May;14(5):475–82. doi: 10.1016/j.jpain.2012.12.013. PMID: 23452825.23452825
153 Gossrau G, Wahner M, Kuschke M, . Microcurrent transcutaneous electric nerve stimulation in painful diabetic neuropathy: a randomized placebo-controlled study. Pain Med. 2011 Jun;12(6):953–60. doi: 10.1111/j.1526-4637.2011.01140.x. PMID: 21627767.21627767
154 Forst T, Nguyen M, Forst S, . Impact of low frequency transcutaneous electrical nerve stimulation on symptomatic diabetic neuropathy using the new Salutaris device. Diabetes Nutr Metab. 2004 Jun;17(3):163–8. PMID: 15334794.15334794
155 Kumar D, Marshall HJ. Diabetic peripheral neuropathy: amelioration of pain with transcutaneous electrostimulation. Diabetes Care. 1997 Nov;20(11):1702–5. PMID: 9353612.9353612
156 Kumar D, Alvaro MS, Julka IS, . Diabetic peripheral neuropathy. Effectiveness of electrotherapy and amitriptyline for symptomatic relief. Diabetes Care. 1998 Aug;21(8):1322–5. PMID: 9702441.9702441
157 Hamza MA, White PF, Craig WF, . Percutaneous electrical nerve stimulation: a novel analgesic therapy for diabetic neuropathic pain. Diabetes Care. 2000 Mar;23(3):365–70. PMID: 10868867.10868867
158 Oyibo SO, Breislin K, Boulton AJ. Electrical stimulation therapy through stocking electrodes for painful diabetic neuropathy: a double blind, controlled crossover study. Diabet Med. 2004 Aug;21(8):940–4. doi: 10.1111/j.1464-5491.2004.01243.x. PMID: 15270803.15270803
159 Lacigova S, Tomesova J, Gruberova J, . “Mesodiencephalic” modulation in the treatment of diabetic neuropathy. Neuro Endocrinol Lett. 2013;34(2):135–42. PMID: 23645311.23645311
160 Bosi E, Bax G, Scionti L, . Frequency-modulated electromagnetic neural stimulation (FREMS) as a treatment for symptomatic diabetic neuropathy: results from a double-blind, randomised, multicentre, long-term, placebo-controlled clinical trial. Diabetologia. 2013 Mar;56(3):467–75. doi: 10.1007/s00125-012-2795-7. PMID: 23238789.23238789
161 Bosi E, Conti M, Vermigli C, . Effectiveness of frequency-modulated electromagnetic neural stimulation in the treatment of painful diabetic neuropathy. Diabetologia. 2005 May;48(5):817–23. doi: 10.1007/s00125-005-1734-2. PMID: 15834546.15834546
162 Weintraub MI, Herrmann DN, Smith AG, . Pulsed Electromagnetic Fields to Reduce Diabetic Neuropathic Pain and Stimulate Neuronal Repair: A Randomized Controlled Trial. Arch Phys Med Rehabil. 2009;90(7):1102–9.19577022
163 Onesti E, Gabriele M, Cambieri C, . H-coil repetitive transcranial magnetic stimulation for pain relief in patients with diabetic neuropathy. European Journal of Pain (United Kingdom). 2013;17(9):1347–56.
164 de Vos CC, Meier K, Zaalberg PB, . Spinal cord stimulation in patients with painful diabetic neuropathy: a multicentre randomized clinical trial. Pain. 2014 Nov;155(11):2426–31. doi: 10.1016/j.pain.2014.08.031. PMID: 25180016.25180016
165 Slangen R, Schaper NC, Faber CG, . Spinal cord stimulation and pain relief in painful diabetic peripheral neuropathy: a prospective two-center randomized controlled trial. Diabetes Care. 2014 Nov;37(11):3016–24. doi: 10.2337/dc14-0684. PMID: 25216508.25216508
166 Macare van Maurik JF, van Hal M, van Eijk RP, . Value of surgical decompression of compressed nerves in the lower extremity in patients with painful diabetic neuropathy: a randomized controlled trial. Plast Reconstr Surg. 2014 Aug;134(2):325–32. doi: 10.1097/prs.0000000000000369. PMID: 24732651.24732651
167 Macare van Maurik JF, Oomen RT, van Hal M, . The effect of lower extremity nerve decompression on health-related quality of life and perception of pain in patients with painful diabetic polyneuropathy: a prospective randomized trial. Diabet Med. 2015 Jun;32(6):803–9. doi: 10.1111/dme.12732. PMID: 25712758.25712758
168 Cohen J. Statistical Power Analysis for the Behavioral Sciences, 2nd ed. Hillsdale, NJ: Erlbaum; 1988.
169 Griebeler ML, Tsapas A, Brito JP, . Pharmacologic interventions for painful diabetic neuropathy: an umbrella systematic review and comparative effectiveness network meta-analysis (Protocol). Syst Rev. 2012;1:61. doi: 10.1186/2046-4053-1-61. PMID: 23198755.23198755
170 Snedecor SJ, Sudharshan L, Cappelleri JC, . Systematic review and meta-analysis of pharmacological therapies for painful diabetic peripheral neuropathy. Pain Pract. 2014 Feb;14(2):167–84. doi: 10.1111/papr.12054. PMID: 23534696.23534696
171 Finnerup NB, Attal N, Haroutounian S, . Pharmacotherapy for neuropathic pain in adults: a systematic review and meta-analysis. Lancet Neurol. 2015 Feb;14(2):162–73. doi: 10.1016/s1474-4422(14)70251-0. PMID: 25575710.25575710
172 Bril V, England JD, Franklin GM, . Evidence-based guideline: treatment of painful diabetic neuropathy--report of the American Association of Neuromuscular and Electrodiagnostic Medicine, the American Academy of Neurology, and the American Academy of Physical Medicine & Rehabilitation. Muscle Nerve. 2011 Jun;43(6):910–7. doi: 10.1002/mus.22092. PMID: 21484835.21484835
173 Dworkin RH, Turk DC, McDermott MP, . Interpreting the clinical importance of group differences in chronic pain clinical trials: IMMPACT recommendations. Pain. 2009 Dec;146(3):238–44. doi: 10.1016/j.pain.2009.08.019. PMID: 19836888.19836888
174 Coffey RJ, Owens ML, Broste SK, . Mortality associated with implantation and management of intrathecal opioid drug infusion systems to treat noncancer pain. Anesthesiology. 2009 Oct;111(4):881–91. doi: 10.1097/ALN.0b013e3181b64ab8. PMID: 20029253.20029253
175 Callaghan BC, Feldman EL. Painful diabetic neuropathy: many similarly effective therapies with widely dissimilar costs. Ann Intern Med. 2014 Nov 4;161(9):674–5. doi: 10.7326/m14-2157. PMID: 25364890.25364890
176 Dworkin RH, Turk DC, Farrar JT, . Core outcome measures for chronic pain clinical trials: IMMPACT recommendations. Pain. 2005 Jan;113 1–2:9–19. doi: 10.1016/j.pain.2004.09.012. PMID: 15621359.15621359
177 Chou R, Turner JA, Devine EB, . The effectiveness and risks of long-term opioid therapy for chronic pain: a systematic review for a National Institutes of Health Pathways to Prevention Workshop. Ann Intern Med. 2015 Feb 17;162(4):276–86. doi: 10.7326/m14-2559. PMID: 25581257.25581257
178 Franklin G. Opioids for chronic noncancer pain: A position paper of the American Academy of Neurology. Neurology. 2014;83(14):1277–84.25267983