# Methods

The methods for this review follow the Agency for Healthcare Research and Quality (AHRQ) Methods Guide for Effectiveness and Comparative Effectiveness Reviews.^26^

## Protocol Development

With input from AHRQ representatives, our panel of technical experts and key informants, we developed a protocol for this systematic review. The final protocol is posted on the AHRQ Effective Health Care Web site: www.effectivehealthcare.ahrq.gov/.

## Data Source and Search Strategy

### Systematic Reviews

We searched PubMed and the Cochrane Database of Systematic Reviews for systematic reviews. We searched for recent reviews from January 1^st^, 2011 to October 12^th^, 2015.

### Primary Studies

For questions where we identified systematic reviews to incorporate, we updated the searches of those reviews by using their search strategy, including the year before the end date of their search. For Key Question (KQ)1b (foot ulcer) and KQ2a, we thus searched for new study publications from January 1^st^, 2013 to May 24, 2016.

For questions where we did not identify high quality relevant systematic reviews, we searched for primary studies using PubMed, Embase®, and the Cochrane Central Register of Controlled Trials (CENTRAL) from inception to May 24, 2016. We developed a search strategy for PubMed based on medical subject headings (MeSH®) terms and text words of relevant reviews and primary studies identified a priori (Appendix B). We limited our search to studies published in English.

As part of a related methods project, we searched the U.S. clinical trials registry (ClinicalTrials.gov) for KQ2a. We used the advanced search function and entered the following terms: diabetic peripheral neuropathy [DISEASE] AND “Interventional” [STUDY-TYPES] AND NOT (“not yet recruiting” OR “terminated” OR “with-drawn”) [OVERALL-STATUS] [Search Date –March 9^th^, 2016].

## Study Selection

### Systematic Reviews

When available, topically relevant and recent reviews were included to answer one or more of the Key Questions. As per the Cochrane Collaboration definition, a systematic review includes a specific research question, a search strategy (e.g., sources such as electronic databases, period covered by the search), and methods used to assess the risk of bias of studies included in the review. Narrative reviews were excluded. We limited our review to those systematic reviews judged to be of low risk of bias (see below for information about how we assessed this for each review).

For additional primary studies we identified that were not included in systematic reviews, two reviewers independently screened the studies based on the PICOTS (populations, interventions, comparators, outcomes, timing, and settings) detailed in Table 1. The studies were excluded if both reviewers agreed that one or more of the exclusion criteria was met. Differences between reviewers regarding abstract eligibility were resolved through consensus.

Table 1 PICOTS (population, interventions, comparators, outcomes, timing, and setting) for the Key Questions

| KQ1a and KQ1b: Preventing Complications of Diabetic Peripheral Neuropathy | KQ2a and KQ2b: Treating Symptoms of Diabetic Peripheral Neuropathy
Population(s) | Adults 18 years of age or older with type 1 or type 2 diabetes at risk for peripheral polyneuropathy | Adults 18 years of age or older with type 1 or type 2 diabetes with peripheral polyneuropathy
Interventions | Pharmacologic treatments focused on glucose control (KQ1a):; - Glucose-lowering strategies (single or combination agents or an intensive control approach using multiple medications): Studies with the goal of glucose control generally include multiple agents and combinations and substitutions and specific agents are not specified. We therefore are not listing the agents here because we are not evaluating specific agents but all glucose-lowering strategies.; Non-pharmacologic and surgical interventions (KQ1b):; - Foot care (daily foot skin temperature measurements and consequent preventative actions, therapeutic footwear, integrated foot care, patient education, self-management); - Surgical interventions for foot ulcers; - Lifestyle interventions (carbohydrate-controlled diet aimed at glucose reduction, weight loss, smoking cessation); - Exercise or balance training or physical therapy modalities | Pharmacologic interventions focused on diabetic peripheral neuropathy (KQ2a): Antidepressants: Tricyclic antidepressants (amitriptyline, amoxapine, clomipramine, desipramine, doxepin, imipramine, maprotiline, nortriptyline, protiptyline, trimipramine), serotonin-noradrenaline reuptake inhibitor antidepressants (desvenlafaxine, duloxetine, levomilnacipran, milnacipran, venlafaxine) Anticonvulsants: pregabalin, gabapentin or gabapentin extended release and enacarbil, other antiepileptics (carbamazepine, lacosamide, lamotrigine, levitiracetam, oxcarbazepine, sodium valproate, tiagabine, topiramate, zonisamide) Analgesics: Opioids (morphine, oxycodone, fentanyl, hydromorphone, methadone, oxymorphone), tramadol, tapentadol Topical Agents: lidocaine, capsaicin, other topical treatments (clonidine,, pentoxyifylline) Other: N-methyl-D-aspartate (NMDA) antagonists (ketamine, dextromethorphan), mexiletine, botulinum toxin A, cannabinoids Combinations of any of the above treatments Non-pharmacologic and surgical interventions (KQ2b):; - Supplements: alpha-lipoic acid, acetyl-L-carnitine; - Acupuncture; - Cognitive-behavioral therapy; - Physical therapy or exercise; - Electrical stimulation (transcutaneous (or percutaneous) electrical nerve stimulation (TENS) or spinal cord stimulator, frequency-modulated electromagnetic neural stimulation, patient-specific electrocutaneous nerve stimulation (Scrambler); - Surgical decompression
Comparators | Active interventions as well as usual care/placebo | Active interventions as well as treatment/placebo
Outcomes^*^ | Benefits (KQ1a and KQ1b):; - Incident or recurrent foot ulcer (excluding healing of ulcer as the outcome); - Falls; - Perceived fall risk; - Amputation; - Health-related quality of life; - Physical activity level; Harms (KQ1a and KQ1b):; - Hypoglycemia (severe and total); - Gastrointestinal side effects, including nausea; - Neuropsychiatric effects (ONLY for smoking cessation studies involving pharmacotherapy); - Cardiovascular events; - Surgical harms; - Dropouts | Benefits (KQ2a and KQ2b):; - Pain; - Paresthesia; - Numbness; - Health-related quality of life (Health-related quality of life is defined using measurement with instruments designed for this topic); Harms (KQ2a and KQ2b):; - Adverse effects reported in >10% of patients and dropouts
Type of Study | Randomized controlled trials, non-randomized studies with a concurrent comparison group | Parallel or crossover randomized controlled trials [must be double-blind (patient and researcher assessing the outcomes) for pharmacologic and others where blinding is possible, such as acupuncture]
Timing and Setting | At least 3 months of followup for pharmacologic interventions and any followup for non-pharmacologic interventions Ambulatory care for all the interventions except surgical interventions | 3 weeks or more of followup Ambulatory care
Language | Study must be published in English

KQ = Key Question

* Outcomes were included that were patient-centered and addressed more than just pain, based on discussion with the Technical Expert Panel.

Health-related quality of life may include areas such as physical health and function, mental health, social and role function, and physical and psychological symptoms

### Primary Studies

We included studies based on the PICOTS (populations, interventions, comparators, outcomes, timing, and settings) detailed in Table 1. For KQ1 we sought randomized controlled trials and non-randomized studies with concurrent comparison groups. For KQ2, we sought randomized controlled trials. Two reviewers independently screened abstracts and, if deemed potentially eligible, full-text versions of the citations. Studies were excluded if both reviewers agreed that one or more of the exclusion criteria was met. Differences between reviewers regarding eligibility were resolved through consensus. We used DistillerSR (Evidence Partners, 2010) to manage the screening process.

Two reviewers independently assessed each ClinicalTrials.gov record for eligibility applying the same eligibility criteria as for the published reports. We screened the ClinicalTrials.gov records using Microsoft Excel 2013 (Microsoft Corporation, Redmond, WA).

Table 2 List of exclusion criteria applied during abstract and full-text screening

Exclusion criteria at abstract screening | - Not evaluating people with type 1 or type 2 diabetes with peripheral neuropathy; - No original data (editorial, commentary); - No full report; - Case series or case reports; - Not in English; - Not conducted in humans; - Study of children only; - Address KQ1a &b but not a RCT or non-randomized with a concurrent comparison group; - Address KQ2a &b but not a parallel or crossover randomized controlled trials; - Drug is not available in the U.S./non-approved(e.g. Investigational )/Not included in the protocol =57; - Not relevant to Key Questions
Additional exclusion criteria at full-text screening | - Not all patients have diabetes in both group; - Addresses KQ1a (pharmacologic intervention) but follow-up less than 3 months; - Addresses KQ2 but follow-up less than 3 weeks; - Study with less than ten patients; - No outcome of interest; - Does not evaluate an intervention of interest

KQ = Key Question, RCT = randomized controlled trial

## Data Extraction and Data Management

We created and pilot tested data extraction forms in Excel (Microsoft, Redmond, WA). Reviewers extracted information on general study characteristics (e.g., study design, study period, followup); eligibility criteria; study participants (e.g., age, gender, race/ethnicity, body mass index, comorbidities, etc.); interventions (including adherence by study participants); outcome measures and the method of ascertainment; and the results of each outcome (continuous and dichotomous data), including measures of variability. We also collected data on outcomes for the subgroups of interest, including age, sex, race/ethnicity, and body mass index.

For pain, paresthesia, numbness outcomes, and neuropathy composite scores, we followed the methods described in the identified review by Griebeler et. al.^2^ Results from one numerical pain score (both continuous and categorical, if reported) were extracted using the following tools hierarchy (see Table 3).

Table 3 Tools hierarchy for numerical pain score

Pain, paresthesia, numbness | Neuropathy composite score
VAS (Visual Analog Scale) | TSS (Total Symptom Score)
NPS (Neuropathic Pain Scale) | NSC (Neuropathy Symptom Change Score) – severity score; LL (lower leg) if both reported
NRS (Numerical Rating Scale) | NTSS (Neuropathy Total Symptom Score)
BPI (Brief Pain Inventory (BPI severity)) | mTCNS (modified Toronto clinical neuropathy score)
McGill | NPSI (neuropathic pain symptom inventory)
SF-MPQ
Other score or numerical scale or Likert

One reviewer completed the data extraction, and a second reviewer checked the first reviewer’s extraction for completeness and accuracy. We resolved differences through discussion and, as needed, through consensus among our team.

We used the data extraction results from the systematic reviews for the included studies and supplemented these with additional data extraction for any outcomes not included in the systematic reviews.

## Risk of Bias Assessment

### Systematic Reviews

Two reviewers assessed risk of bias of relevant systematic reviews using the ROBIS tool. This tool uses categories of yes, probably yes, probably no, no, no information across four domains (study eligibility criteria; identification and selection of studies; data collection and study appraisal; and synthesis and findings).^27^ The overall assessment for each systematic review is based on a reviewer’s overall judgement given their response to the individual ROBIS items, and has three overall ratings: Low, High, and Unclear. An independent reviewer resolved any discrepancies regarding the ROBIS tool assessment between the reviewers.

### Primary Studies

For primary studies included in systematic reviews, we relied on the risk of bias assessments as performed in the systematic reviews. For newly identified studies, two reviewers independently assessed risk of bias. We used the Cochrane Collaboration Tool for assessing the risk of bias of controlled studies.^28^ For non-randomized studies of treatment interventions, we used the Cochrane Risk of Bias Assessment Tool for Non-Randomized Studies of Interventions (ACROBAT-NRSI).^29^ We completed risk of bias assessment for any studies uniquely identified from ClinicalTrials.gov using the same tools (i.e., Cochrane Risk of Bias tool). Differences between reviewers were resolved through consensus.

## Data Synthesis

For each Key Question, we created a detailed set of evidence tables containing all of the information abstracted from the newly identified studies. All studies were summarized qualitatively. We did not abstract data for primary studies included in systematic reviews; we relied on the information provided in the review. We conducted meta-analyses for an outcome when there were sufficient data (at least three studies of the same design) and studies were sufficiently homogenous with respect to key variables (population characteristics, intervention, and outcome measurement) using a profile likelihood estimate for a random effects model. All meta-analyses were conducted using STATA 12.1 (College Station, TX). Pain scales reported in the included studies were standardized by estimating the standardized mean difference using the Cohen d method. When possible, for studies that did not include variability measures, the standard deviation of change in mean was calculated using a correlation coefficient of 0.5, in accordance with methods provided in Fu et al (2013). ^30^

## Strength of the Body of Evidence

After synthesizing the evidence, two reviewers graded the body of evidence for each KQ using the evidence grading scheme recommended in the Methods Guide for Effectiveness and Comparative Effectiveness Reviews.^26^ In assigning evidence grades, we considered the five recommended domains, including study limitation in the included studies, directness of the evidence, consistency across studies, precision, and reporting bias. We assessed the aggregate risk of bias of individual studies and integrated these assessments into a qualitative summary risk of bias rating across studies of similar interventions for each outcome.

We classified the strength of evidence pertaining to the KQs and critical outcomes into four basic categories or grades: high, moderate, low, and insufficient (see Table 4). The strength of evidence was based on the totality of evidence (i.e., evidence in prior reviews as well as new evidence) where we included an existing systematic review.

Table 4 Strength of evidence grades and definitions

Grade | Definition
High | We are very confident that the estimate of effect lies close to the true effect for this outcome. The body of evidence has few or no deficiencies. We believe that the findings are stable.
Moderate | We are moderately confident that the estimate of effect lies close to the true effect for this outcome. The body of evidence has some deficiencies. We believe that the findings are likely to be stable, but some doubt remains.
Low | We have limited confidence that the estimate of effect lies close to the true effect for this outcome. The body of evidence has major or numerous deficiencies (or both). We believe that additional evidence is needed before concluding either that the findings are stable or that the estimate of effect is close to the true effect.
Insufficient | We have no evidence, we are unable to estimate an effect, or we have no confidence in the estimate of effect for this outcome. The body of evidence may have unacceptable deficiencies, precluding judgment.

We graded the strength of evidence for the outcomes we classified as most important or critical during protocol development: pain, health-related quality of life, falls, foot ulcers, and amputation. The investigators writing each section completed the strength of evidence grading. Throughout the report writing process, team members reviewed the grading and discussed the process used to grade the evidence.

## Applicability

Applicability was assessed separately for the different outcomes and was guided by the PICOTS framework as recommended in the Methods Guide for Comparative Effectiveness Reviews of Interventions.^26^ We considered important population characteristics (age, gender, race, ethnicity, duration and severity of diabetes) and intervention features that may cause heterogeneity of treatment effects, and issues such as length of followup that may affect generalizability of the findings.

## Peer Review and Public Comment

A full draft report was reviewed by experts and posted for public commentary from June 8th, 2016, through July 7th, 2016. Comments received from invited reviewers and through the public comment website were compiled and addressed. A disposition of comments will be posted on the Effective Health Care Program Web site 3 months after the release of the evidence report.