# Introduction

## Background

### Diabetic Peripheral Neuropathy

According to an estimate from the Centers for Disease Control (CDC), 29.1 million people, or 9.3 percent of the U.S. population, have diabetes.^1^ Thirty to 50 percent of patients with diabetes will eventually develop nerve damage called neuropathy.^2^ Clinical diabetic neuropathy has been categorized into distinct syndromes according to the neurologic distribution, but many overlapping syndromes occur. Feldman et al.^3^ classified diabetic neuropathy into several categories:

1. Distal symmetric sensorimotor polyneuropathy ^4^
2. Autonomic neuropathy
3. Thoracic and lumbar polyradiculopathies due to nerve root disease
4. Individual cranial and peripheral nerve involvement causing focal mononeuropathies
5. Asymmetric involvement of multiple peripheral nerves, resulting in a mononeuropathy multiplex

Studies have found that peripheral neuropathy (which includes any disorder of the peripheral nervous system, including polyneuropathy, polyradiculopathies, and mononeuropathy, as listed above) occurs in up to half of the population with diabetes. In one study of patients with diabetic neuropathy, more than 50 percent had distal symmetric sensorimotor polyneuropathy, and other neuropathies included median mononeuropathies (25%), autonomic neuropathy (7%), thoracic and lumbar polyradiculopathy and cranial mononeuropathies (3%).^5^ A recent expert panel report from the Diabetic Neuropathy Study Group of the European Association for the Study of Diabetes (NEURODIAB) defined diabetic polyneuropathy as a “symmetrical, length-dependent sensorimotor polyneuropathy attributable to metabolic and microvessel alterations as a result of chronic hyperglycemia exposure (diabetes) and cardiovascular risk covariates”.^6^ For the purposes of this review, we use the term diabetic peripheral neuropathy as the symmetrical sensorimotor polyneuropathy of the hands and feet.

The earliest signs of diabetic peripheral neuropathy are loss of vibratory sensation and altered proprioception caused by large-fiber loss and impairment of pain, light touch, and temperature caused by loss of small nerve fibers.^3^ Diabetic peripheral neuropathy is usually described as glove-stocking distribution of numbness, sensory loss, paresthesia (abnormal sensation) and/or pain (shooting or stabbing). Sensory loss from neuropathy increases risk for foot injury, delayed treatment (since injuries are not noticed by the patient immediately), and foot and leg ulceration and infections. Recurrent ulcers and infections may eventually lead to amputation of the lower extremities. Altered proprioception causes imbalance and increased risk for falls. Painful neuropathy may lead to reduced ability to perform daily activities and a decrease in quality of life.^7^ Complications of diabetic peripheral neuropathy include secondary diseases or conditions that develop in the course of diabetic peripheral neuropathy, such as foot ulcers. Symptoms are defined as the subjective experience of diabetic peripheral neuropathy and include numbness and pain.

### Interventions

#### Pharmacologic Treatment Options To Prevent Complications

The cornerstone of pharmacologic interventions to prevent complications of diabetic peripheral neuropathy is medications and strategies that improve glucose control.^8^ Key pharmacologic interventions that address comorbid conditions in patients with diabetes are statins and antihypertensives. These agents may also contribute to preventing diabetic peripheral neuropathy complications,^9^ since co-existing peripheral vascular disease can contribute to long-term diabetic complications, such as foot ulcerations.^10^ Although diabetic peripheral neuropathy is not an outcome in studies addressing these comorbid conditions, they may be described as important comorbidities in studies of glucose control that report on diabetic neuropathy outcomes.

#### Nonpharmacologic Treatment Options To Prevent Complications

These interventions include non-pharmacologic glucose control interventions, such as diet and exercise, and interventions to prevent specific complications, such as foot care for prevention of foot ulcers, as well as exercise and balance training for the prevention of falls.

#### Pharmacologic Treatment Options To Improve Symptoms

A variety of pharmacological approaches has been evaluated to reduce pain and improve health-related quality of life through a number of mechanisms. These include drugs with direct impact on neurotransmitters and inhibitory pathways or drugs that bind to opioid receptors. Several medications are Food And Drug Administration ( FDA) approved for diabetic peripheral neuropathy (e.g., pregabalin) or other types of neuropathy (e.g., gabapentin, lidocaine patches for herpes zoster), but most are approved for other indications (e.g., depression, seizure disorders) and evaluated and used off-label for painful diabetic peripheral neuropathy. For diabetic peripheral neuropathy, pain is the most commonly studied symptom in the literature, although other symptoms, such as paresthesia, that are less commonly addressed in trials are also important to patients.

#### Nonpharmacologic Treatment Options To Improve Symptoms

These interventions also focus mainly on treating pain. Although there is less evidence in this area, modalities that have been evaluated specifically for diabetic peripheral neuropathy and addressed in previous, reviews include acupuncture, physical therapy and exercise, electrical stimulation, and surgical decompression.

### Available Evidence and Shortcomings

#### Prevention of Complications (Foot Ulcers, Falls, and Perceived Fall Risk)

For pharmacologic and lifestyle interventions, prior reviews have mainly addressed medications for glucose control [which have been evaluated in multiple reviews, including recent and ongoing Evidence-based Practice Center (EPC) reviews on oral diabetes medications which have generally not evaluated neuropathy as an outcome], ^11–13^ lifestyle interventions, and a variety of quality improvement strategies (such as care management) previously included in the EPC review Closing the Quality Gap Series.^14^ A recent Cochrane review focused on the prevention of diabetic peripheral neuropathy included 17 randomized controlled trials.^15^ The review reported a significantly reduced risk of developing clinical polyneuropathy among patients with type 1 diabetes with intensive glucose control after five years of followup (annualized risk difference −1.84%), but a non-significantly reduced risk of −0.58 percent (95% confidence interval [CI], 0.01 to −1.17) in patients with type 2 diabetes and intensive glucose control. This review is currently being updated.

For nonpharmacologic interventions, some systematic reviews have addressed specific interventions, such as exercise training or improving footwear.^16, 17^ The International Working Group on the Diabetic Foot (IWGDF) conducted a systematic review to investigate the effectiveness of interventions (i.e., care intervention, self-management intervention, medical intervention) to prevent first and recurrent foot ulcers or amputation in persons with diabetes who are at-risk for complications.^18^ This review found moderate evidence supporting the home-monitoring of foot skin temperatures with subsequent preventative actions and the use of therapeutic footwear with a demonstrated pressure-relieving effect consistently worn by the patient. There was some evidence to suggest that prevention of a recurrent foot ulcer by integrated foot care is effective. Surgical interventions can be effective in selected patients, but the evidence is limited.

A variety of pharmacological and non-pharmacological approaches have been evaluated for preventing complications of diabetic peripheral neuropathy. However, complications other than foot ulcers and amputations have not been comprehensively addressed in recent reviews or guidelines.

#### Treatment of Symptoms (Pain, Paresthesia, Numbness)

Treatments for diabetic peripheral neuropathy symptoms were last reviewed comprehensively by an American Association of Neuromuscular and Electrodiagnostic Medicine, American Academy of Neurology, and American Academy of Physical Medicine & Rehabilitation systematic review and guideline, published in 2011, that reviewed literature through 2008. This review addressed a variety of issues with treatment but focused mainly on pharmacotherapy and the outcome of pain. The guideline recommended only pregabalin as an effective treatment and recommended several other antidepressants and anticonvulsants, tramadol, and capsaicin, as well as opioids, as probably effective. For non-pharmacological interventions, only percutaneous electrical nerve stimulation was recommended as “should be considered”.

Since the completion of this review and guideline, new trials have been conducted on the drugs evaluated in this review and related medications. One additional agent has been FDA-approved for treatment of painful neuropathy: the high-dose capsaicin patch.

Many newer reviews focusing on pharmacologic treatment of painful neuropathy have reported on effectiveness for a number of agents, but not for diabetic peripheral neuropathy specifically, or addressed only certain drug classes or specific drugs.^19–24^ The most recently published review (published in February 2015), developed by the NeuPSIG (Special Interest Group on Neuropathic Pain of the International Association for the Study of Pain) to update their clinical recommendations, addressed all causes of peripheral neuropathy and recommended a number of agents.^22^ The review assessed a broad range of interventions as moderate- to high-quality evidence, including serotonin-norepinephrine reuptake inhibitors (specifically, duloxetine) and gabapentin. Two comprehensive systematic reviews focusing solely on pharmacologic interventions for painful diabetic peripheral neuropathy were published in 2014,^2,,25^ but these reviews focused only on pain, did not synthesize evidence on other symptoms (numbness and paresthesia), health-related quality of life or dropouts due to adverse effects, and did not search for unpublished studies, which are common in this area. No recent reviews have comprehensively covered nonpharmacologic interventions.

## Scope and Key Questions

We conducted a systematic review on pharmacological and non-pharmacological interventions for the prevention of diabetic peripheral neuropathy complications and treatment of diabetic peripheral neuropathy symptoms. We developed an analytic framework to illustrate the different questions and outcomes we considered (Figure 1), and we sought to address the following Key Questions:

Key Question 1a What are the benefits and harms of pharmacologic treatment options focused on glucose lowering to prevent the [underlined: complications] of diabetic peripheral neuropathy among adults age 18 or older with type 1 or type 2 diabetes mellitus?
Key Question 1b What are the benefits and harms of non-pharmacologic treatment options (foot care, surgical interventions, dietary strategies, lifestyle interventions, exercise, and balance training) to prevent [underlined: complications] of diabetic peripheral neuropathy among adults age 18 or older with type 1 or type 2 diabetes mellitus?
Key Question 2a What are the benefits and harms of pharmacologic treatment options to improve the [underlined: symptoms] of diabetic peripheral neuropathy and health-related quality of life among adults age 18 or older with type 1 or type 2 diabetes mellitus?
Key Question 2b What are the benefits and harms of non-pharmacologic treatment options (alpha-lipoic acid, acetyl-L-carnitine, acupuncture, physical therapy and exercise, cognitive behavioral therapy, electrical stimulation, surgical decompression) to improve the [underlined: symptoms] of diabetic peripheral neuropathy and health-related quality of life among adults age 18 or older with type 1 or type 2 diabetes mellitus?

Figure 1 Analytic framework for effectiveness of treatments for diabetic peripheral neuropathy

KQ=Key Question

^*^ Only for smoking cessation studies involving phamacotherapy

Figure 1. Analytic Framework for effectiveness of treatments for diabetic peripheral neuropathy. The figure shows the preliminary analytic framework which describes the key question 1a (pharmacologic treatment options to prevent the complications), key questions 1b (non-pharmacologic treatment options prevent the complications), key question 2a (pharmacologic treatment options to improve the symptoms), and key question 2b (non-pharmacologic treatment options to improve the symptoms). Moving from left to right, there is text, arrows, boxes and circles that have text within and around. The first thing on the left shows the group with type 1 or type 2 diabetes with diabetic peripheral neuropathy. There are two arrows pointing to intervention denoting key question 1a, key questions 1b, key question 2a, and key question 2b. The interventions for KQ1a include pharmacologic treatments (Glucose-lowering strategies), KQ1b include non-pharmacologic and surgical interventions (foot care, surgical, lifestyle, exercise, balance training, physical therapy), KQ2a include pharmacologic interventions (antidepressants, anticonvulsants, analgesics, and topical agents) and KQ2b include non-pharmacologic and surgical interventions (supplements, acupuncture, cognitive-behavioral therapy, physical therapy or exercise, electrical stimulation, surgical decompression). There is an arrow that points to a circle labeled adverse effects which denotes KQ1 and b. The adverse effects include hypoglycemia (severe and total), gastrointestinal side effects, including nausea, neuropsychiatric effects (only for smoking cessation studies involving pharmacotherapy), cardiovascular events, surgical harms, dropouts. There is an arrow pointing to outcomes of the intervention denoting KQ1a and b. The intermediate outcomes include incident or recurrent foot ulcer, falls, perceived fall risk, amputation, health-related quality of life, and physical activity level. There is an arrow that pointing down to a circle labeled adverse effects which denotes KQ2a and b. The adverse effects include adverse effects reported in >10% of patients and all dropouts[10% is generally considered a threshold for common adverse effects. Adverse effects over 10% are reported in the studies and compiled in systematic reviews. Serious adverse effects (including death) are reported as dropouts due to adverse effects]. There is an arrow pointing to outcomes of the intervention denoting KQ2 and b. The outcomes include pain, paresthesias, numbness, health-related quality of life.