# Technical Expert Panel

In designing the study questions and methodology at the outset of this report, the EPC consulted several technical and content experts. Broad expertise and perspectives were sought. Divergent and conflicting opinions are common and perceived as healthy scientific discourse that results in a thoughtful, relevant systematic review. Therefore, in the end, study questions, design, methodological approaches, and/or conclusions do not necessarily represent the views of individual technical and content experts.

Technical Experts must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential conflicts of interest identified.

The list of Technical Experts who provided input to this report follows:

- Marina Basina, M.D.^*^
  Stanford University Medical Center
  Stanford, CA
- John D. England, M.D., FAAN
  Louisiana State University
  New Orleans, LA
- Robert G. Frykberg, D.P.M., M.P.H.
  University of Arizona College of Medicine
  Phoenix, AZ
- Ewan McNicol, R.Ph., M.S.P.R.E.P.^*^
  Tufts Medical Center/Tufts University
  Boston, MA
- Bijan Najafi, Ph.D., M.Sc.
  Baylor College of Medicine
  Houston, TX
- Pushpa Narayanaswami, M.D., FAAN^*^
  Harvard Medical School/Beth Israel Deaconess Medical Center
  Boston, MA

* Provided input on Draft Report.