# Key Informants

In designing the study questions, the EPC consulted several Key Informants who represent the end-users of research. The EPC sought the Key Informant input on the priority areas for research and synthesis. Key Informants are not involved in the analysis of the evidence or the writing of the report. Therefore, in the end, study questions, design, methodological approaches, and/or conclusions do not necessarily represent the views of individual Key Informants.

Key Informants must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their role as end-users, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any conflicts of interest identified.

The list of Key Informants who provided input to this report follows:

- Miroslav “Misha” Bačkonja, M.D.
  University of Wisconsin
  Madison, WI
- Eva L. Feldman, M.D., Ph.D.
  University of Michigan Health System
  Ann Arbor, MI
- Thomas S. D. Getchius, B.A.
  American Academy of Neurology
  Minneapolis, MN
- Edward Gregg, Ph.D.
  Centers for Disease Control and Prevention
  Atlanta, GA
- Cindy Lamendola, R.N., M.S.N., N.P.
  Stanford University
  Stanford, CA
- Ewan McNicol, R.Ph., M.S.P.R.E.P.
  Tufts Medical Center/Tufts University
  Boston, MA
- Pam Shlemon
  The Foundation for Peripheral Neuropathy
  Buffalo Grove, IL
- Jan S. Ulbrecht, M.D.
  Pennsylvania State University
  University Park, PA
- Douglas Zochodne, M.D., FRCPC
  University of Alberta
  Edmonton, AB, Canada