# Acknowledgments

The authors gratefully acknowledge the support of our AHRQ Task Order Officer, Aysegul Gozu, M.D., M.P.H. We thank our Associate Editor, Timothy Wilt, M.D., M.P.H., for revisions and commentary. We thank Jeanette Edelstein, M.A., for copy editing the report. We extend our appreciation to our Key Informants and members of our Technical Expert Panel.