# Appendix E Strength of Evidence

Table E-1 Strength of evidence domains for pharmacologic treatment for the prevention of diabetic foot ulcers and lower extremity amputations (KQ1a)

Key Outcomes | Study Design: No. Studies (N)^a^ | Study Limitation | Directness | Consistency | Precision | Reporting Bias | Other Issues | Key Findings | Strength of Evidence
Foot ulcer
Intensive vs. standard glycemic control | 2 RCTs in patients with Type 1 DM n=1,329 | Moderate^a^ | Direct | Consistent | Imprecise | Unsuspected | Few event rates. | Two RCTs reported no significant differences between intensive vs standard glycemic control for prevention of foot ulcers (RR 0.32, 95% CI, 0.10 to 1.06 and 0.37, 95% CI 0.12 to 1.15), but the number of events was low despite long followup periods | Low
Intensive vs. standard glycemic control | 2 RCTs in patients with Type 2 DM n=1,326 | Moderate^a^ | Direct | Consistent | Imprecise | Unsuspected | None | Two RCTs reported no significant difference between arms. | Low
Monotherapy or combination medications | 1 cohort study in patients with Type 2 DM n=23,395 | High^b^ | Direct | Unknown | Imprecise | Unsuspected | None | A cohort study reported reduced hazard ratio (HR: 0.6, 95% CI: 0.38 to 0.98) for foot ulcers for patients taking glargine insulin versus NPH insulin. | Insufficient
Lower extremity amputations
Intensive vs. standard glycemic control | 1 RCT in patients with Type 1 DM n=1,257 | Low | Direct | Unknown | Imprecise | Unsuspected | None | One RCT did not show a statistically significant differences between lower extremity amputations in the intensive vs. standard glycemic control arms in patients with Type 1 diabetes. | Low
Intensive vs. standard glycemic control | 5 RCTs in patients with Type 2 DM n=9,348 | Low | Direct | Consistent | Imprecise | Unsuspected | None | Five RCTs reported a decreased risk of lower extremity amputations in the intensive vs. standard glycemic control arms. (Pooled RR 0.63, 95% CI 0.40 to 0.96). | Moderate
Comparisons of monotherapy or combination medications | 1 RCT in patients with Type 2 DM n=5,238 | Low | Direct | Unknown | Imprecise | Unsuspected | None | One RCT that compared pioglitazone versus placebo reported no significant difference in risk of amputations between the two arms. | Low

a Moderate because of studies’ lack of clarity about how outcomes assessed and ascertained for foot ulcers

b High limitations because of study design as single observational study. Non-randomized design contributes significant risk of bias and limitations.

CI=Confidence Interval; DM=Diabetes Mellitus; N=sample size; OR=odds ratio; RCT=Randomized Controlled Trial

Table E-2 Strength of evidence domains for non-pharmacologic treatment for the prevention of diabetic foot ulcers (KQ1b)

Key Outcomes | Study Design: No. Studies (N) | Study Limitation | Directness | Consistency | Precision | Reporting Bias | Other Issues | Key Findings | Strength of Evidence
Diabetic foot ulcers
Integrated foot care | 3 RCTs and 1 cohort n=350 | Medium | Direct | Consistent | Precise | Unsuspected | None | Netten et al. reported a reduction in foot ulcer incidence or recurrence using integrated care. The reduction was ~20% across studies. We did not identify new studies in our updated search | Low
Self-management: home monitoring of foot temperature | 4 RCTs n=583 | Low | Direct | Consistent | Precise | Unsuspected | None | 3 RCTs from Netten et al. showed reduction in incident foot ulcers in patients using self-monitoring of foot temperature compared with standard of care. One newly identified RCT was consistent with Netten et al. | Moderate
Self-management: Topical treatment on foot | 1 RCT and 1 cohort n=360 | High | Direct | Inconsistent | Imprecise | Unsuspected | None | Inconsistent findings from one RCT from Netten et al. and one newly identified cohort study | Insufficient
Patient Education | 3 RCTs and 1 cohort n=16,943 | Medium | Direct | Inconsistent | Imprecise | Unsuspected | None | Netten et al. review concluded that there was no reduction in ulcer recurrence from one time educational programs, based on two RCTs 2 newly identified studies (1 RCT and 1 cohort) did not change this finding | Low
Therapeutic footwear | 7 RCTs and 3 cohorts n=1,913 | Medium | Direct | Inconsistent | Imprecise | Unsuspected | None | Netten et al. concluded that specific modalities of therapeutic footwear could be effective in the prevention of a recurrent plantar foot ulcer compared with more standard-of-care therapeutic footwear. The risk reduction ranged from 4% to 45% across studies. We did not identify new studies in our updated search | Moderate
Surgical Intervention | 3 RCTs and 6 cohort n=744 | high | Direct | Inconsistent | Imprecise | Unsuspected | None | Netten et al. concluded that surgical interventions (Achilles tendon lengthening, single or pan-metatarsal head resection and metatarsophalangeal joint arthroplasty) appear to reduce ulcer recurrence risk in a range from 24% to 43% in some patients with initially non-healing ulcers when compared with non-surgical treatment. We did not identify new studies in our updated search | Low
Lower extremity amputations
Integrated Foot Care | 2 RCTs and 2 cohorts n=27,840 | Medium | Direct | Inconsistent | Imprecise | Unsuspected | None | We are unable to draw any conclusions. | Insufficient
Self-management | 1 RCT n=85 | High | Direct | Unknown | Imprecise | Unsuspected | None | We are unable to draw any conclusions. | Insufficient
Patient Education: | 2 RCTs and 1 cohort n=16,812 | Medium | Direct | Consistent | Precise | Unsuspected | None | 1 RCT from Netten et al. reported no benefit from a single educational session about amputation (RR 1.0; 95% CI, 0.91 to 1.11). 2 newly identified studies (1 RCT and 1 cohort study) did not report any benefit from a single education session. Results from all three studies suggested that education programs did not change the occurrence of amputation. | Low
Therapeutic Footwear | 1 cohort n=46 | High | Direct | Consistent | Precise | Unsuspected | None | We are unable to draw any conclusions. | Insufficient
Surgical Intervention | 2 cohorts n=168 | High | Direct | Inconsistent | Imprecise | Unsuspected | None | We are unable to draw any conclusions. | Insufficient
Quality of life
Home-monitoring of foot temperature | 1 RCT N=85 | High | Direct | Unknown | Imprecise | Unsuspected | None | We are unable to draw any conclusions. | Insufficient
Surgical interventions | 1 RCT N=28 | High | Direct | Unknown | Imprecise | Unsuspected | None | We are unable to draw any conclusions. | Insufficient

CI=Confidence Interval; DM=Diabetes Mellitus; N=sample size; OR=odds ratio; RCT=Randomized Controlled Trial

Table E-3 Strength of evidence domains for balance training intervention on outcomes of falls, foot ulcer and quality of life (KQ1b)

Key Outcomes | Study Design: No. Studies (N) | Study Limitation | Directness | Consistency | Precision | Reporting Bias | Other Issues | Key Findings | Strength of Evidence
Falls
Balance training vs. control^*^ | 1 RCT (reported in 2 studies) n= 79 | Low | Direct | Unknown | Imprecise | Unsuspected | None | One RCT reported no statistically significant difference in falls between the balance training group and the control group (2.06 versus 2.02 falls/1000 person-days, respectively) and differences were not statistically significant. We were unable to draw any conclusions. | Insufficient
Exercise training vs. control^*^ | 1 RCT (reported in 2 studies) n= 79 | Low | Direct | Unknown | Imprecise | Unsuspected | None | One RCT reported no statistically significant difference in falls between the balance training group and the control group (2.06 versus 2.02 falls/1000 person-days, respectively) and differences were not statistically significant. We were unable to draw any conclusions. | Insufficient
Foot ulcer
Exercise training vs. control^*^ | 1 RCTs (reported in 2 studies) 1 prospective cohort study n=469 | Moderate | Direct | Consistent | Imprecise | Unsuspected | None | Rate Ratio of all foot ulcers is 1.24; 95% CI, 0.70 to 2.19 reported in 1 RCT Another prospective study showed incidence of re-ulceration 16.5% in the least active group, 13.4% in the moderately active group, and 13% in the most active group We were unable to draw any conclusions. | Insufficient
Physical therapy vs. control | 1 RCT n=29 | Low | Direct | Unknown | Imprecise | Unsuspected | None | Reported number of ulcers in weight bearing versus non-weight bearing groups: 1 vs 3 We were unable to draw any conclusions. | Insufficient
Quality of Life
Balance training vs. control | 1 RCT n= 39 | Low | Direct | Unknown | Imprecise | Unsuspected | None | The difference between the study arms in the mean difference from baseline was 0.29, in the direction favoring the intervention group, not statistically significantly different. We were unable to draw any conclusions. | Insufficient
Exercise training vs. control^*^ | 1 RCT n=87 | Low | Direct | Unknown | Imprecise | Unsuspected | None | % change from baseline for intervention and control was 28.40 in the direction favoring the intervention group, p<0.001). We were unable to draw any conclusions. | Insufficient

CI = confidence interval; DM = diabetes mellitus; N = sample size; p = p-value; RCT = randomized controlled trial

High limitations because of study design as single observational study. Non-randomized design contributes significant risk of bias and limitations.

* Same study included under both interventions

Table E-4 Strength of evidence domains for studies comparing individual drugs with placebo in terms of pain and quality of life among adults with diabetic peripheral neuropathy (KQ2a)

Source | Key Outcomes | Study Design: No. Studies (N) | Study Limitation | Consistency | Directness | Precision | Reporting Bias | Other Issues | Key Findings | Strength of Evidence
Gabapentin vs. Placebo
Published literature + CT.gov | Pain | 5 RCTs n=833 | Unclear | Inconsistent | Direct | Precise | Suspected | Newest studies did not find evidence of effectiveness. | Gabapentin does not improve pain more than placebo. | Low
Published literature + CT.gov | Quality of life | 3 RCTs n=646 | Unclear | Inconsistent | Direct | Could not be evaluated | Suspected | | Given incomplete reporting of results, we were unable to draw any conclusions. | Insufficient
Pregabalin vs. Placebo
Published literature + CT.gov | Pain | 16 RCTs n=4,712 | Unclear | Inconsistent | Direct | Precise | Suspected | Newer and unpublished studies did not find evidence of effectiveness | Pregabalin is more effective than placebo for reducing pain. However, effect size is small and pregabalin may be less effective than what would be estimated from the published literature alone. | Low
Published literature + CT.gov | Quality of life | 10 RCTs n=3,513 | Unclear | Inconsistent | Direct | Could not be evaluated | Suspected | | Given incomplete reporting of results, we were unable to draw any conclusions. | Insufficient
Oxcarbazepine vs. Placebo
Published literature | Pain | 3 RCTs n=634 | Unclear | Inconsistent | Direct | Imprecise | Suspected | Studies were only 16 weeks in duration. | Oxcarbazepine is more effective than placebo at reducing pain, but data was incompletely reported. | Low
Published literature | Quality of life | 3 RCTs n=634 | Unclear | Inconsistent | Direct | Could not be evaluated | Suspected | | Given incomplete reporting of results, we were unable to draw any conclusions. | Insufficient
Lacosamide vs. Placebo^*^
Published literature + CT.gov | Pain | 4 RCTs n=1,626 | Unclear | Inconsistent | Direct | Imprecise | Suspected | | Lacosamide is not more effective than placebo at reducing pain. | Low
Published literature + CT.gov | Quality of life | 1 RCT n=119 | Unclear | NA | Direct | Could not be evaluated | Suspected^*^ | | We are unable to draw a conclusion. | Insufficient
Oxycodone vs. Placebo
Published literature + CT.gov | Pain | 4 RCTs n=638 | Unclear | Inconsistent | Direct | Imprecise | Suspected | | Opioids are not more effective than placebo for reducing pain. | Low
Duloxetine vs. Placebo
Published literature | Pain | 7 RCTs n= ,2203 | Unclear | Consistent | Direct | Precise | Unsuspected | | Duloxetine reduced pain more than placebo | Moderate
Published literature | Quality of life | 4 RCTs n=1,112 | Unclear | Inconsistent | Direct | Could not be evaluated | Suspected | | Given incomplete reporting of results, we were unable to draw any conclusions. | Insufficient
Venlafaxine vs. Placebo
Published literature | Pain | 2 RCTs n=304 | Unclear | Consistent | Direct | Precise | Unsuspected | | Venlafaxine reduced pain more than placebo. | Moderate
Capsaicin 0.075% vs. Placebo
Published literature + CT.gov | Pain | 5 RCTs n= 411 | Unclear | Inconsistent | Direct | Imprecise | Suspected | | Capsaicin is not more effective than placebo for reducing pain. | Low
Capsaicin 8% vs. Placebo
Published literature + CT.gov | Pain | 1 RCT n=369 | Unclear | Unknown | Direct | Imprecise | Suspected | Study was not published | We are unable to draw a conclusion. | Insufficient
Published literature + CT.gov | Quality of life | 1 RCT n=369 | Unclear | Unknown | Direct | Imprecise | Suspected | | We are unable to draw a conclusion. | Insufficient
Clonidine vs. Placebo
Published literature + CT.gov | Pain | 1 RCT n= 369 | Unclear | Unknown | Direct | Imprecise | Suspected | Study was not published | We are unable to draw a conclusion. | Insufficient
Nabilone vs. Placebo
Published literature + CT.gov | Pain | 1 RCT n= 60 | Unclear | Unknown | Direct | Imprecise | Unsuspected | | We are unable to draw a conclusion. | Insufficient
Published literature + CT.gov | Quality of life | 1RCT n= 60 | Unclear | Unknown | Direct | Imprecise | Unsuspected | | We are unable to draw a conclusion. | Insufficient
Nabiximols vs. Placebo
Published literature + CT.gov | Pain | 1 RCT n= 297 | Unclear | Unknown | Direct | Imprecise | Suspected | | We are unable to draw a conclusion. | Insufficient
Published literature + CT.gov | Quality of life | 1 RCT n= 297 | Unclear | Unknown | Direct | Imprecise | Suspected | | We are unable to draw a conclusion. | Insufficient
Tramadol vs. Placebo
Published literature | Pain | RCTs: 2 n=444 | Unclear | Inconsistent | Direct | Precise | Unsuspected | | Tramadol reduced pain more than placebo. | Low
Published literature | Quality of Life | RCTs: 2 n=444 | Unclear | Inconsistent | Direct | Could not be evaluated | Suspected | | Given incomplete reporting of results, we were unable to draw any conclusions. | Insufficient
Tapentadol vs. Placebo
Published literature | Pain | RCTs: 3 n=737 | Unclear | Consistent | Direct | Precise | Unsuspected | | Tapentadol reduced pain more than placebo. | Low
Published literature | Quality of Life | RCTs: 2 n=342 | Unclear | Inconsistent | Direct | Could not be evaluated | Suspected | | Given incomplete reporting of results, we were unable to draw any conclusions. | Insufficient
Botulinum vs. Placebo
Published literature | Pain | RCTs: 2 n=80 | Unclear | Inconsistent | Direct | imprecise | suspected | | Botulinum toxin reduced pain more than placebo | Low
Dextromethorphan vs. Placebo
Published literature | Pain | RCTs: 3 n=416 | Unclear | Inconsistent | Direct | Imprecise | Unsuspected | | Dextromethorphan did not reduce pain more than placebo | Low
Mexiletine vs. Placebo
Published literature | Pain | RCTs: 5 n=389 | Unclear | Inconsistent | Direct | Imprecise | Unsuspected | | Mexiletine did not reduce pain more than placebo | Low
Duloxetine vs. Pregabalin
Published literature | Pain | RCTs: 2 n=411 | Unclear | Consistent | Direct | Could not be evaluated | Suspected | | Given incomplete reporting of results, we were unable to draw any conclusions.. | Insufficient

CT.gov = ClinicalTrials.gov; N = sample size; NA = not available; RCT = randomized controlled trial; vs = versus

* All four of the studies for lacosamide vs placebo identified in both the published literature and ClinicalTrials.gov listed quality of life as an outcome. However, only one study included quality of life in their publication.

† Note that only key individual drug comparisons are listed in these tables; others were included as part of drug classes or were insufficient.

Table E-5 Strength of evidence for studies comparing [underlined: drug classes with placebo] in terms of pain and quality of life among adults with diabetic peripheral neuropathy (KQ2a)

Key Outcomes | Study Design: No. Studies (N) | Study Limitation | Directness | Consistency | Precision | Reporting Bias | Other Issues | Key Findings | Strength of Evidence
Serotonin-noradrenaline reuptake inhibitors vs. Placebo
Pain | RCT: 10 n=2,507 | Unclear | Direct | Consistent | Precise | Unsuspected | | SNRIs reduced pain more than placebo | Moderate
Quality of Life | RCT: 6 n=1,925 | Unclear | Direct | Inconsistent | Could not be evaluated | Unsuspected | | Given incomplete reporting of results, we were unable to draw any conclusions. | Insufficient
Tricyclic antidepressants vs. Placebo
Pain | RCT: 4 n=(81) | High | Direct | Inconsistent | Imprecise | Unsuspected | | Tricyclic antidepressants reduced pain more than placebo | Low
Atypical Opioids vs. Placebo
Pain | RCT: 5 n=1,181 | Unclear | Direct | Consistent | Precise | Unsuspected | Methodology inconsistent with pain trial standards | Atypical opioids reduced pain more than placebo | Low
Quality of Life | RCT: 4 n=786 | Unclear | Direct | Inconsistent | Could not be evaluated | Unsuspected | | Given incomplete reporting of results, we were unable to draw any conclusions. | Insufficient
Opioids vs. Placebo
Pain | RCT: 4 n=638 | Unclear | Direct | Inconsistent | Imprecise | Suspected | | Opioids did not reduce pain more than placebo | Low

N=sample size; RCT=randomized controlled trial; vs=versus

* For quality of life, evidence was insufficient for opioids (oxycodone), Where results are not reported above for quality of life, there were no studies that evaluated this outcome for the drug class compared with placebo (e.g., tricyclic antidepressants).

Table E-6 Strength of evidence domain for the non-pharmacologic interventions (KQ2b)

Key Outcomes | Study Design: No. Studies (N) | Study Limitation | Directness | Consistency | Precision | Reporting Bias | Other Issues | Key Findings | Strength of Evidence
Alpha-lipoic acid vs. placebo
Pain | RCT: 5 n=984 | Unclear | Direct | Consistent | Precise | Suspected; not all studies reported on pain subscale separately (although onluded in the composite score) | Dose-response: absent; Strength of association: medium | Alpha lipoic acid reduced pain scores moderately more than placebo, but studies were limited by inconsistent outcome reporting and other bias | Low
Transcutaneous electrical nerve stimulation vs. sham
Pain | RCT: 4 n=118 | Unclear | Direct | Inconsistent | Imprecise | Unsuspected | Dose-response: absent | Transcutaneous electrical nerve stimulation did not reduce pain scores more than sham, although studies were small | Low
Frequency-modulated electromagnetic stimulation vs. sham
Pain | RCT: 2 n=132 | Unclear | Direct | Inconsistent | Imprecise | Unsuspected | Intervention effects did not last long-term | Frequency-modulated electromagnetic stimulation reduced pain short-term more than placebo, but not long-term | Low
Spinal cord stimulation vs. usual care
Pain | RCT: 2 n=96 | Low | Direct | Consistent | Precise | Unsuspected | Strength of association: large; Trial run-in period, no sham arm | Spinal cord stimulation reduced pain scores more than usual care | Low
Quality of Life | RCT: 2 n=96 | Unclear | Direct | Inconsistent | Imprecise | Unsuspected | Run-in period, no sham arm | Standardized mean difference could not be calculated given incomplete data, but one study found a statistically significant difference and one did not. Spinal cord stimulation is not more effective than usual care for improving quality of life. | Insufficient

N=sample size; RCT=randomized controlled trial; vs=versus

* Note that other interventions or outcomes had only one small size study, and strength of evidence was therefore insufficient