# Appendix D Evidence Tables

Evidence Table D-1 Study characteristics for pharmacological treatment (KQ1a)

Evidence Table D-2 Patient characteristics for pharmacological treatment (KQ1a)

Evidence Table D-3 Outcomes for pharmacological treatment (KQ1a)

Evidence Table D-4 Harms for pharmacological treatment (KQ1a)

Evidence Table D-5 Study and participant characteristics for balance intervention (KQ1b)

Evidence Table D-6 Balance intervention characteristics (KQ1b)

Evidence Table D-7 Incident or recurrent foot ulcer outcomes for balance intervention (KQ1b)

Evidence Table D-8 Falls outcomes for balance intervention (KQ1b)

Evidence Table D-9 Perceived fall risk for balance intervention (KQ1b)

Evidence Table D-10 Quality of life for balance intervention (KQ1b)

Evidence Table D-11 Physical activity level for balance intervention (KQ1b)

Evidence Table D-12 Drop outs for balance intervention (KQ1b)

Evidence Table D-13 Study characteristics for exercise intervention (KQ1b)

Evidence Table D-14 Exercise interventions characteristics (KQ1b)

Evidence Table D-15 Exercise intervention-participant characteristics (KQ1b)

Evidence Table D-16 Exercise intervention - physical activity level (KQ1b)

Evidence Table D-17 Exercise intervention - incidence or reoccurrence of ulcers outcome (KQ1b)

Evidence Table D-18 Exercise intervention - quality of life outcome (KQ1b)

Evidence Table D-19 Exercise intervention - harms (KQ1b)

Evidence Table D-20 Study characteristics for physical therapy interventions (KQ1b)

Evidence Table D-21 Physical therapy interventions characteristics (KQ1b)

Evidence Table D-22 Physical therapy intervention - participant characteristics (KQ1b)

Evidence Table D-23 Physical therapy intervention - physical activity level (KQ1b)

Evidence Table D-24 Physical therapy intervention incidence or reoccurrence of ulcers outcome (KQ1b)

Evidence Table D-25 Study characteristics for lifestyle intervention (KQ1b)

Evidence Table D-26 Lifestyle intervention - participant characteristics (KQ1b)

Evidence Table D-27 Lifestyle intervention outcomes (KQ1b)

## Foot care intervention

The evidence tables from the Netten et al review are available at: http://www.iwgdf.org/files/2015/PreventionSR.pdf

The data from the newly identified tables are described in the following tables:

Evidence Table D-28 Study characteristics for foot care intervention (KQ1b)

Evidence Table D-29 Foot care intervention - participant characteristics (KQ1b)

Evidence Table D-30 Foot care interventions characteristics (KQ1b)

Evidence Table D-31 Footcare intervention – ulcer incidence or recurrent outcome (KQ1b)

Evidence Table D-32 Footcare intervention - lower extremity amputation outcome (KQ1b)

Evidence Table D-33 Footcare intervention - harms (KQ1b)

Evidence Table D-34 Surgery intervention - patient characteristics (KQ1b)

Evidence Table D-35 Surgery interventions characteristics (KQ1b)

Evidence Table D-36 Surgery intervention - ulcer incidence or recurrent outcome (KQ1b)

Evidence Table D-37 Surgery intervention - quality of life outcome (KQ1b)

Evidence Table D-38 Surgery intervention - physical activity level (KQ1b)

Evidence Table D-39 Risk of bias for RCTs (KQ1a)

Evidence Table D-40 Risk of bias for cohort studies (KQ1a)

Evidence Table D-41 Risk of bias for RCTs (KQ1b)

Evidence Table D-42 Risk of bias for cohort studies (KQ1b)

### References for Tables D-1 to D-42

1 Knatterud GL, Klimt CR, Levin ME, . Effects of hypoglycemic agents on vascular complications in patients with adult-onset diabetes. VII. Mortality and selected nonfatal events with insulin treatment. JAMA. 1978;240(1):37–42.351218
2 Reichard P, Nilsson BY, U. R. The effect of long-term intensified insulin treatment on the development of microvascular complications of diabetes mellitus. N Engl J Med. 1993;329(5):304–9.8147960
3 Rathsman B, Jensen-Urstad K, Nystrom T. Intensified insulin treatment is associated with improvement in skin microcirculation and ischaemic foot ulcer in patients with type 1 diabetes mellitus: a long-term follow-up study. Diabetologia. 2014 Aug;57(8):1703–10. doi: 10.1007/s00125-014-3248-2. PMID: 24802206.24802206
4 Abraira C, Colwell J, Nuttall F, . Cardiovascular events and correlates in the Veterans Affairs Diabetes Feasibility Trial. Veterans Affairs Cooperative Study on Glycemic Control and Complications in Type II Diabetes. Arch Intern Med. 1997;157(2):181–8.9009975
5 Intensive blood-glucose control with sulphonylureas or insulin compared with conventional treatment and risk of complications in patients with type 2 diabetes (UKPDS 33). UK Prospective Diabetes Study (UKPDS) Group. Lancet. 1998 Sep 12;352(9131):837–53. PMID: 9742976.9742976
6 Gaede P, Vedel P, Larsen N, . Multifactorial intervention and cardiovascular disease in patients with type 2 diabetes. N Engl J Med. 2003 Jan 30;348(5):383–93. doi: 10.1056/NEJMoa021778. PMID: 12556541.12556541
7 Gaede P, Lund-Andersen H, Parving HH, . Effect of a multifactorial intervention on mortality in type 2 diabetes. N Engl J Med. 2008 Feb 7;358(6):580–91. doi: 10.1056/NEJMoa0706245. PMID: 18256393.18256393
8 Dormandy JA, Charbonnel B, Eckland DJ, . Secondary prevention of macrovascular events in patients with type 2 diabetes in the PROactive Study (PROspective pioglitAzone Clinical Trial In macroVascular Events): a randomised controlled trial. Lancet. 2005 Oct 8;366(9493):1279–89. doi: 10.1016/S0140-6736(05)67528-9. PMID: 16214598.16214598
9 Martin CL, Albers J, Herman WH, . Neuropathy among the diabetes control and complications trial cohort 8 years after trial completion. Diabetes Care. 2006 Feb;29(2):340–4. PMID: 16443884.16443884
10 The effect of intensive treatment of diabetes on the development and progression of long-term complications in insulin-dependent diabetes mellitus. The Diabetes Control and Complications Trial Research Group. N Engl J Med. 1993 Sep 30;329(14):977–86. doi: 10.1056/NEJM199309303291401. PMID: 8366922.8366922
11 Duckworth W, Abraira C, Moritz T, . Glucose control and vascular complications in veterans with type 2 diabetes. N Engl J Med. 2009 Jan 8;360(2):129–39. doi: 10.1056/NEJMoa0808431. PMID: 19092145.19092145
12 Griffin SJ, Borch-Johnsen K, Davies MJ, . Effect of early intensive multifactorial therapy on 5-year cardiovascular outcomes in individuals with type 2 diabetes detected by screening (ADDITION-Europe): a cluster-randomised trial. Lancet. 2011;378(9786):156–67. PMID: 21705063.21705063
13 Araki A, Iimuro S, Sakurai T, . apanese Elderly Diabetes Intervention Trial Study Group. Long-term multiple risk factor interventions in Japanese elderly diabetic patients: the Japanese Elderly Diabetes Intervention Trial--study design, baseline characteristics and effects of intervention. Geriatr Gerontol Int. 2012;Suppl 1:7–17.22435936
14 Kostev K, Dippel FW, Rockel T, . Risk of diabetic foot ulceration during treatment with insulin glargine and NPH insulin. J Wound Care. 2012 Oct;21(10):483–4, 6–9. doi: 10.12968/jowc.2012.21.10.483. PMID: 23103482.23103482
15 Jaiswal M, Martin CL, Brown MB, . Effects of exenatide on measures of diabetic neuropathy in subjects with type 2 diabetes: results from an 18-month proof-of-concept open-label randomized study. J Diabetes Complications. 2015 Jul 17 10.1016/j.jdiacomp.2015.07.013. PMID: 26264399.26264399
16 Effect of intensive blood-glucose control with metformin on complications in overweight patients with type 2 diabetes (UKPDS 34). UK Prospective Diabetes Study (UKPDS) Group. Lancet. 1998 Sep 12;352(9131):854–65. PMID: 9742977.9742977
17 Simmons RK, Sharp SJ, Sandbæk A, . Does early intensive multifactorial treatment reduce total cardiovascular burden in individuals with screen-detected diabetes? Findings from the ADDITION-Europe cluster-randomized trial. Diabet Med. 2012;29(11):e409–16.22823477
18 Richardson JK, Sandman D, Vela S. A focused exercise regimen improves clinical measures of balance in patients with peripheral neuropathy. Arch Phys Med Rehabil. 2001 Feb;82(2):205–9. doi: 10.1053/apmr.2001.19742. PMID: 11239311.11239311
19 Kruse RL, Lemaster JW, Madsen RW. Fall and balance outcomes after an intervention to promote leg strength, balance, and walking in people with diabetic peripheral neuropathy: “feet first” randomized controlled trial. Phys Ther. 2010 Nov;90(11):1568–79. doi: 10.2522/ptj.20090362. PMID: 20798179.20798179
20 Lemaster JW, Mueller MJ, Reiber GE, . Effect of weight-bearing activity on foot ulcer incidence in people with diabetic peripheral neuropathy: feet first randomized controlled trial. Phys Ther. 2008 Nov;88(11):1385–98. doi: 10.2522/ptj.20080019. PMID: 18801859.18801859
21 Song CH, Petrofsky JS, Lee SW, . Effects of an exercise program on balance and trunk proprioception in older adults with diabetic neuropathies. Diabetes Technol Ther. 2011 Aug;13(8):803–11. doi: 10.1089/dia.2011.0036. PMID: 21561371.21561371
22 Lee K, Lee S, Song C. Whole-body vibration training improves balance, muscle strength and glycosylated hemoglobin in elderly patients with diabetic neuropathy. Tohoku J Exp Med. 2013;231(4):305–14. PMID: 24334483.24334483
23 Eftekhar-Sadat B, Azizi R, Aliasgharzadeh A, . Effect of balance training with Biodex Stability System on balance in diabetic neuropathy. Ther Adv Endocrinol Metab. 2015 Oct;6(5):233–40. doi: 10.1177/2042018815595566. PMID: 26445646.26445646
24 Grewal GS, Schwenk M, Lee-Eng J, . Sensor-Based Interactive Balance Training with Visual Joint Movement Feedback for Improving Postural Stability in Diabetics with Peripheral Neuropathy: A Randomized Controlled Trial. Gerontology. 2015 Feb 19 10.1159/000371846. PMID: 25721132.25721132
25 Kordi Yoosefinejad A, Shadmehr A, Olyaei G, . Short-term effects of the whole-body vibration on the balance and muscle strength of type 2 diabetic patients with peripheral neuropathy: a quasi-randomized-controlled trial study. J Diabetes Metab Disord. 2015;14:45. doi: 10.1186/s40200-015-0173-y. PMID: 26052508.26052508
26 Sartor CD, Hasue RH, Cacciari LP, . Effects of strengthening, stretching and functional training on foot function in patients with diabetic neuropathy: results of a randomized controlled trial. BMC Musculoskelet Disord. 2014;15:137. doi: 10.1186/1471-2474-15-137. PMID: 24767584.24767584
27 Lemaster JW, Reiber GE, Smith DG, . Daily weight-bearing activity does not increase the risk of diabetic foot ulcers. Med Sci Sports Exerc. 2003 Jul;35(7):1093–9. doi: 10.1249/01.mss.0000074459.41029.75. PMID: 12840628.12840628
28 Dixit S, Maiya A, Shastry B. Effect of aerobic exercise on quality of life in population with diabetic peripheral neuropathy in type 2 diabetes: a single blind, randomized controlled trial. Qual Life Res. 2014 Jun;23(5):1629–40. doi: 10.1007/s11136-013-0602-7. PMID: 24326731.24326731
29 Taveggia G, Villafane JH, Vavassori F, . Multimodal treatment of distal sensorimotor polyneuropathy in diabetic patients: a randomized clinical trial. J Manipulative Physiol Ther. 2014 May;37(4):242–52. doi: 10.1016/j.jmpt.2013.09.007. PMID: 24656867.24656867
30 Mueller MJ, Tuttle LJ, Lemaster JW, . Weight-bearing versus nonweight-bearing exercise for persons with diabetes and peripheral neuropathy: a randomized controlled trial. Arch Phys Med Rehabil. 2013 May;94(5):829–38. doi: 10.1016/j.apmr.2012.12.015. PMID: 23276801.23276801
31 Chatchawan U, Eungpinichpong W, Plandee P, . Effects of thai foot massage on balance performance in diabetic patients with peripheral neuropathy: a randomized parallel-controlled trial. Med Sci Monit Basic Res. 2015;21:68–75. doi: 10.12659/msmbr.894163. PMID: 25892354.25892354
32 Bunner AE, Wells CL, Gonzales J, . A dietary intervention for chronic diabetic neuropathy pain: a randomized controlled pilot study. Nutr Diabetes. 2015;5:e158. doi: 10.1038/nutd.2015.8. PMID: 26011582.26011582
33 Skafjeld A, Iversen MM, Holme I, . A pilot study testing the feasibility of skin temperature monitoring to reduce recurrent foot ulcers in patients with diabetes - a randomized controlled trial. BMC Endocr Disord. 2015;15(1):55. doi: 10.1186/s12902-015-0054-x. PMID: 26452544.26452544
34 Shah BR, Hwee J, Cauch-Dudek K, . Diabetes self-management education is not associated with a reduction in long-term diabetes complications: An effectiveness study in an elderly population. J Eval Clin Pract. 2015;21(4):656–61.25847059
35 Monami M, Zannoni S, Gaias M, . Effects of a Short Educational Program for the Prevention of Foot Ulcers in High-Risk Patients: A Randomized Controlled Trial. Int J Endocrinol. 2015;2015:615680. doi: 10.1155/2015/615680. PMID: 26448748.26448748
36 Gibson TB, Driver VR, Wrobel JS, . Podiatrist care and outcomes for patients with diabetes and foot ulcer. Int Wound J. 2014 Dec;11(6):641–8. doi: 10.1111/iwj.12021. PMID: 23374540.23374540
37 Chin YF, Liang J, Wang WS, . The role of foot self-care behavior on developing foot ulcers in diabetic patients with peripheral neuropathy: a prospective study. Int J Nurs Stud. 2014 Dec;51(12):1568–74. doi: 10.1016/j.ijnurstu.2014.05.001. PMID: 24866324.24866324
38 Mueller MJ, Sinacore DR, Hastings MK, . Impact of achilles tendon lengthening on functional limitations and perceived disability in people with a neuropathic plantar ulcer. Diabetes Care. 2004 Jul;27(7):1559–64. PMID: 15220228.15220228

## Evidence Tables for KQ2a and b

The evidence tables from the Griebeler et al review are available at: http://www.ncbi.nlm.nih.gov/pubmed/23198755

The data from the newly identified tables are described in the following tables:

Evidence Table D-43 Study characteristics for pharmacological treatments (KQ2a)

Evidence Table D-44 Participant characteristics for pharmacological treatments (KQ2a)

Evidence Table D-45 Intervention characteristics for pharmacological treatments (KQ2a)

Evidence Table D-46 Pain continuous outcomes for pharmacological treatments (KQ2a)

Evidence Table D-47 Pain categorical outcomes for pharmacological treatments (KQ2a)

Evidence Table D-48 Paresthesias outcomes for pharmacological treatments (KQ2a)

Evidence Table D-49 Quality of life outcomes for pharmacological treatments (KQ2a)

Evidence Table D-50 Harms for pharmacological treatments (KQ2a)

Evidence Table D-51 Drop outs for pharmacological treatments (KQ2a)

Evidence Table D-52 Summary of findings from Griebler et al. (2014) review (KQ2a)

Evidence Table D-53 Summary of network meta-analysis findings from Griebler et al. (2014) review (KQ2a)

Evidence Table D-54 List of additional outcomes from Griebler et al. (2014) (KQ2a)

Evidence Table D-55 List of additional numbness outcomes from Griebler et al. (2014) (KQ2a)

Evidence Table D-56 List of additional parasthesias outcomes from Griebler et al. (2014) (KQ2a)

Evidence Table D-57 Quality of life outcome from Griebler review (KQ2a)

Evidence Table D-58 Dropouts reported in Griebler review (KQ2a)

Evidence Table D-59 Study and intervention characteristics of supplement intervention (KQ2b)

Evidence Table D-60 Patient characteristics of supplement intervention (KQ2b)

Evidence Table D-61 Supplement intervention - pain continuous outcomes (KQ2b)

Evidence Table D-62 Supplement intervention - composite outcomes categorical total symptom score (KQ2b)

Evidence Table D-63 Supplement intervention - neuropathy symptom change severity (KQ2b)

Evidence Table D-64 Supplement intervention - pain categorical outcomes (KQ2b)

Evidence Table D-65 Supplement intervention - paresthesia continuous outcomes (KQ2b)

Evidence Table D-66 Supplement intervention - numbness continuous outcome (KQ2b)

Evidence Table D-67 Supplement intervention - harms (KQ2b)

Evidence Table D-68 Supplement intervention - dropouts (KQ2b)

Evidence Table D-69 Acupuncture intervention - study characteristics (KQ2b)

Evidence Table D-70 Acupuncture interventions characteristics (KQ2b)

Evidence Table D-71 Acupuncture intervention - participant characteristics

Evidence Table D-72 Acupuncture intervention - pain continuous outcomes (KQ 2b)

Evidence Table D-73 Acupuncture intervention - quality of life (KQ2b)

Evidence Table D-74 Acupuncture intervention - harms (KQ2b)

Evidence Table D-75 Study characteristics of cognitive therapy intervention (KQ2b)

Evidence Table D-76 Cognitive therapy intervention - participant characteristics (KQ2b)

Evidence Table D-77 Cognitive therapy interventions characteristics (KQ2b)

Evidence Table D-78 Cognitive therapy intervention - pain continuous outcomes (KQ2b)

Evidence Table D-79 Study characteristics of electrical stimulation intervention (KQ2b)

Evidence Table D-80 Electrical stimulation intervention - participant characteristics (KQ2b)

Evidence Table D-81 Electrical stimulation interventions characteristics (KQ2b)

Evidence Table D-82 Electrical stimulation intervention - pain continuous outcomes (KQ2b)

Evidence Table D-83 Electrical stimulation intervention - pain categorical outcomes (KQ2b)

Evidence Table D-84 Electrical stimulation intervention - composite pain outcomes (KQ2b)

Evidence Table D-85 Electrical stimulation intervention - paresthesia outcome (KQ2b)

Evidence Table D-86 Electrical stimulation intervention - numbness outcome (KQ2b)

Evidence Table D-87 Electrical stimulation intervention - quality of life outcome (KQ2b)

Evidence Table D-88 Electrical stimulation intervention - dropouts (KQ2b)

Evidence Table D-89 Study characteristics of frequency-modulated electromagnetic neural stimulation intervention (KQ2b)

Evidence Table D-90 Frequency-modulated electromagnetic neural stimulation intervention - participant characteristics (KQ2b)

Evidence Table D-91 Frequency-modulated electromagnetic neural stimulation intervention characteristics (KQ2b)

Evidence Table D-92 Frequency-modulated electromagnetic neural stimulation intervention - pain continuous outcomes (KQ2b)

Evidence Table D-93 Frequency-modulated electromagnetic neural stimulation intervention - quality of life (KQ2b)

Evidence Table D-94 Frequency-modulated electromagnetic neural stimulation intervention - dropouts (KQ2b)

Evidence Table D-95 Study characteristics of surgical decompression (KQ2b)

Evidence Table D-96 Surgical decompression intervention - participants characteristics (KQ2b)

Evidence Table D-97 Surgical decompression interventions characteristics (KQ2b)

Evidence Table D-98 Surgical decompression pain continuous outcome (KQ2b)

Evidence Table D-99 Surgical decompression quality of life (KQ2b)

Evidence Table D-100 Study characteristics of spinal cord stimulation intervention (KQ2b)

Evidence Table D-101 Spinal cord stimulation intervention - participant characteristics (KQ2b)

Evidence Table D-102 Spinal cord stimulation interventions characteristics (KQ2b)

Evidence Table D-103 Spinal cord stimulation intervention - pain continuous outcomes (KQ2b)

Evidence Table D-104 Spinal cord stimulation intervention - pain categorical outcomes (KQ2b)

Evidence Table D-105 Spinal cord stimulation intervention - quality of life (KQ2b)

Evidence Table D-106 Spinal cord stimulation intervention - dropouts (KQ2b)

Evidence Table D-107 Risk of bias for RCTs (KQ2a)

Evidence Table D-108 Risk of bias for RCTs (KQ2b)

### References for Tables D-43 to D-108

1 Allen R, Sharma U, Barlas S. Clinical experience with desvenlafaxine in treatment of pain associated with diabetic peripheral neuropathy. J Pain Res. 2014;7:339–51. doi: 10.2147/jpr.s55682. PMID: 25018648.25018648
2 Arezzo JC, Rosenstock J, Lamoreaux L, . Efficacy and safety of pregabalin 600 mg/d for treating painful diabetic peripheral neuropathy: a double-blind placebo-controlled trial. BMC Neurol. 2008;8:33. doi: 10.1186/1471-2377-8-33. PMID: 18796160.18796160
3 Atli A, Dogra S. Zonisamide in the treatment of painful diabetic neuropathy: a randomized, double-blind, placebo-controlled pilot study. Pain Med. 2005 May–Jun;6(3):225–34. 10.1111/j.1526-4637.2005.05035.x. PMID: 15972086.15972086
4 Campbell CM, Kipnes MS, Stouch BC, . Randomized control trial of topical clonidine for treatment of painful diabetic neuropathy. Pain. 2012 Sep;153(9):1815–23. doi: 10.1016/j.pain.2012.04.014. PMID: 22683276.22683276
5 Chad DA, Aronin N, Lundstrom R, . Does capsaicin relieve the pain of diabetic neuropathy? Pain. 1990 Sep;42(3):387–8. PMID: 1701234.1701234
6 Freeman R, McIntosh KA, Vijapurkar U, . Topiramate and physiologic measures of nerve function in polyneuropathy. Acta Neurol Scand. 2007 Apr;115(4):222–31. doi: 10.1111/j.1600-0404.2006.00789.x. PMID: 17376119.17376119
7 Gao Y, Guo X, Han P, . Treatment of patients with diabetic peripheral neuropathic pain in China: a double-blind randomised trial of duloxetine vs. placebo. Int J Clin Pract. 2015 Sep;69(9):957–66. doi: 10.1111/ijcp.12641. PMID: 25939897.25939897
8 Ghasemi M, Ansari M, Basiri K, . The effects of intradermal botulinum toxin type a injections on pain symptoms of patients with diabetic neuropathy. J Res Med Sci. 2014 Feb;19(2):106–11. PMID: 24778662.24778662
9 Hanna M, O’Brien C, Wilson MC. Prolonged-release oxycodone enhances the effects of existing gabapentin therapy in painful diabetic neuropathy patients. Eur J Pain. 2008 Aug;12(6):804–13. doi: 10.1016/j.ejpain.2007.12.010. PMID: 18262450.18262450
10 Harati Y, Gooch C, Swenson M, . Double-blind randomized trial of tramadol for the treatment of the pain of diabetic neuropathy. Neurology. 1998 Jun;50(6):1842–6. PMID: 9633738.9633738
11 Jiang W, Ladd S, Martsberger C, . Effects of pregabalin on heart rate variability in patients with painful diabetic neuropathy. J Clin Psychopharmacol. 2011 Apr;31(2):207–13. doi: 10.1097/JCP.0b013e31820f4f57. PMID: 21346609.21346609
12 Karmakar S, Rashidian H, Chan C, . Investigating the role of neuropathic pain relief in decreasing gait variability in diabetes mellitus patients with neuropathic pain: a randomized, double-blind crossover trial. J Neuroeng Rehabil. 2014;11:125. doi: 10.1186/1743-0003-11-125. PMID: 25139539.25139539
13 Kulkantrakorn K, Lorsuwansiri C, Meesawatsom P. 0.025% capsaicin gel for the treatment of painful diabetic neuropathy: a randomized, double-blind, crossover, placebo-controlled trial. Pain Pract. 2013 Jul;13(6):497–503. doi: 10.1111/papr.12013. PMID: 23228119.23228119
14 Niesters M, Proto PL, Aarts L, . Tapentadol potentiates descending pain inhibition in chronic pain patients with diabetic polyneuropathy. Br J Anaesth. 2014 Jul;113(1):148–56. doi: 10.1093/bja/aeu056. PMID: 24713310.24713310
15 Raskin P, Huffman C, Toth C, . Pregabalin in patients with inadequately treated painful diabetic peripheral neuropathy: a randomized withdrawal trial. Clin J Pain. 2014 May;30(5):379–90. doi: 10.1097/AJP.0b013e31829ea1a1. PMID: 23887339.23887339
16 Rauck R, Makumi CW, Schwartz S, . A randomized, controlled trial of gabapentin enacarbil in subjects with neuropathic pain associated with diabetic peripheral neuropathy. Pain Pract. 2013 Jul;13(6):485–96. doi: 10.1111/papr.12014. PMID: 23186035.23186035
17 Rowbotham MC, Arslanian A, Nothaft W, . Efficacy and safety of the alpha4beta2 neuronal nicotinic receptor agonist ABT-894 in patients with diabetic peripheral neuropathic pain. Pain. 2012 Apr;153(4):862–8. doi: 10.1016/j.pain.2012.01.009. PMID: 22386472.22386472
18 Sandercock D, Cramer M, Biton V, . A gastroretentive gabapentin formulation for the treatment of painful diabetic peripheral neuropathy: efficacy and tolerability in a double-blind, randomized, controlled clinical trial. Diabetes Res Clin Pract. 2012 Sep;97(3):438–45. doi: 10.1016/j.diabres.2012.03.010. PMID: 22497967.22497967
19 Schwartz S, Etropolski MS, Shapiro DY, . A pooled analysis evaluating the efficacy and tolerability of tapentadol extended release for chronic, painful diabetic peripheral neuropathy. Clin Drug Investig. 2015 Feb;35(2):95–108. doi: 10.1007/s40261-014-0249-3. PMID: 25503082.25503082
20 Shaibani AI, Pope LE, Thisted R, . Efficacy and safety of dextromethorphan/quinidine at two dosage levels for diabetic neuropathic pain: a double-blind, placebo-controlled, multicenter study. Pain Med. 2012 Feb;13(2):243–54. doi: 10.1111/j.1526-4637.2011.01316.x. PMID: 22314263.22314263
21 Tesfaye S, Wilhelm S, Lledo A, . Duloxetine and pregabalin: high-dose monotherapy or their combination? The “COMBO-DN study”--a multinational, randomized, double-blind, parallel-group study in patients with diabetic peripheral neuropathic pain. Pain. 2013 Dec;154(12):2616–25. doi: 10.1016/j.pain.2013.05.043. PMID: 23732189.23732189
22 Toth C, Mawani S, Brady S, . An enriched-enrolment, randomized withdrawal, flexible-dose, double-blind, placebo-controlled, parallel assignment efficacy study of nabilone as adjuvant in the treatment of diabetic peripheral neuropathic pain. Pain. 2012 Oct;153(10):2073–82. doi: 10.1016/j.pain.2012.06.024. PMID: 22921260.22921260
23 Vinik AI, Shapiro DY, Rauschkolb C, . A randomized withdrawal, placebo-controlled study evaluating the efficacy and tolerability of tapentadol extended release in patients with chronic painful diabetic peripheral neuropathy. Diabetes Care. 2014 Aug;37(8):2302–9. doi: 10.2337/dc13-2291. PMID: 24848284.24848284
24 Yuan RY, Sheu JJ, Yu JM, . Botulinum toxin for diabetic neuropathic pain: a randomized double-blind crossover trial. Neurology. 2009 Apr 28;72(17):1473–8. doi: 10.1212/01.wnl.0000345968.05959.cf. PMID: 19246421.19246421
25 Ziegler D, Duan WR, An G, . A randomized double-blind, placebo-, and active-controlled study of T-type calcium channel blocker ABT-639 in patients with diabetic peripheral neuropathic pain. Pain. 2015 Oct;156(10):2013–20. doi: 10.1097/j.pain.0000000000000263. PMID: 26067585.26067585
26 Backonja M, Beydoun A, Edwards KR, . Gabapentin for the symptomatic treatment of painful neuropathy in patients with diabetes mellitus: a randomized controlled trial. JAMA. 1998 Dec 2;280(21):1831–6. PMID: 9846777.9846777
27 Bansal D, Bhansali A, Hota D, . Amitriptyline vs. pregabalin in painful diabetic neuropathy: a randomized double blind clinical trial. Diabet Med. 2009 Oct;26(10):1019–26. doi: 10.1111/j.1464-5491.2009.02806.x. PMID: 19900234.19900234
28 Beydoun A, Shaibani A, Hopwood M, . Oxcarbazepine in painful diabetic neuropathy: results of a dose-ranging study. Acta Neurol Scand. 2006 Jun;113(6):395–404. doi: 10.1111/j.1600-0404.2006.00631.x. PMID: 16674606.16674606
29 Boyle J, Eriksson ME, Gribble L, . Randomized, placebo-controlled comparison of amitriptyline, duloxetine, and pregabalin in patients with chronic diabetic peripheral neuropathic pain: impact on pain, polysomnographic sleep, daytime functioning, and quality of life. Diabetes Care. 2012 Dec;35(12):2451–8. doi: 10.2337/dc12-0656. PMID: 22991449.22991449
30 Treatment of painful diabetic neuropathy with topical capsaicin. A multicenter, double-blind, vehicle-controlled study. The Capsaicin Study Group. Arch Intern Med. 1991 Nov;151(11):2225–9. PMID: 1953227.1953227
31 Dejgard A, Petersen P, Kastrup J. Mexiletine for treatment of chronic painful diabetic neuropathy. Lancet. 1988 Jan 2–9;1(8575–6):9–11. PMID: 2891940.2891940
32 Dogra S, Beydoun S, Mazzola J, . Oxcarbazepine in painful diabetic neuropathy: a randomized, placebo-controlled study. Eur J Pain. 2005 Oct;9(5):543–54. doi: 10.1016/j.ejpain.2004.11.006. PMID: 16139183.16139183
33 Eisenberg E, Lurie Y, Braker C, . Lamotrigine reduces painful diabetic neuropathy: a randomized, controlled study. Neurology. 2001 Aug 14;57(3):505–9. PMID: 11502921.11502921
34 Freeman R, Raskin P, Hewitt DJ, . Randomized study of tramadol/acetaminophen versus placebo in painful diabetic peripheral neuropathy. Curr Med Res Opin. 2007 Jan;23(1):147–61. doi: 10.1185/030079906x162674. PMID: 17257476.17257476
35 Freynhagen R, Strojek K, Griesing T, . Efficacy of pregabalin in neuropathic pain evaluated in a 12-week, randomised, double-blind, multicentre, placebo-controlled trial of flexible- and fixed-dose regimens. Pain. 2005 Jun;115(3):254–63. doi: 10.1016/j.pain.2005.02.032. PMID: 15911152.15911152
36 Gao Y, Ning G, Jia WP, . Duloxetine versus placebo in the treatment of patients with diabetic neuropathic pain in China. Chin Med J (Engl). 2010 Nov;123(22):3184–92. PMID: 21163113.21163113
37 Gimbel JS, Richards P, Portenoy RK. Controlled-release oxycodone for pain in diabetic neuropathy: a randomized controlled trial. Neurology. 2003 Mar 25;60(6):927–34. PMID: 12654955.12654955
38 Goldstein DJ, Lu Y, Detke MJ, . Duloxetine vs. placebo in patients with painful diabetic neuropathy. Pain. 2005 Jul;116 1–2:109–18. doi: 10.1016/j.pain.2005.03.029. PMID: 15927394.15927394
39 Grosskopf J, Mazzola J, Wan Y, . A randomized, placebo-controlled study of oxcarbazepine in painful diabetic neuropathy. Acta Neurol Scand. 2006 Sep;114(3):177–80. doi: 10.1111/j.1600-0404.2005.00559.x. PMID: 16911345.16911345
40 Jia H, Li Q, Song D, . Effects of venlafaxine and carbamazepine for painful peripheral diabetic neuropathy: a randomized double blind and double dummy controlled multicenter trial. Chinese Journal of Evidence-Based Medicine. 2006;6:321–7.
41 Jose VM, Bhansali A, Hota D, . Randomized double-blind study comparing the efficacy and safety of lamotrigine and amitriptyline in painful diabetic neuropathy. Diabet Med. 2007 Apr;24(4):377–83. doi: 10.1111/j.1464-5491.2007.02093.x. PMID: 17335465.17335465
42 Kochar DK, Jain N, Agarwal RP, . Sodium valproate in the management of painful neuropathy in type 2 diabetes - a randomized placebo controlled study. Acta Neurol Scand. 2002 Nov;106(5):248–52. PMID: 12371916.12371916
43 Kochar DK, Rawat N, Agrawal RP, . Sodium valproate for painful diabetic neuropathy: a randomized double-blind placebo-controlled study. QJM. 2004 Jan;97(1):33–8. PMID: 14702509.14702509
44 Kvinesdal B, Molin J, Froland A, . Imipramine treatment of painful diabetic neuropathy. JAMA. 1984 Apr 6;251(13):1727–30. PMID: 6366276.6366276
45 Lesser H, Sharma U, LaMoreaux L, . Pregabalin relieves symptoms of painful diabetic neuropathy: a randomized controlled trial. Neurology. 2004 Dec 14;63(11):2104–10. PMID: 15596757.15596757
46 Max MB, Kishore-Kumar R, Schafer SC, . Efficacy of desipramine in painful diabetic neuropathy: a placebo-controlled trial. Pain. 1991 Apr;45(1):3–9; discussion 1–2. PMID: 1861872.1861872
47 Max MB, Lynch SA, Muir J, . Effects of desipramine, amitriptyline, and fluoxetine on pain in diabetic neuropathy. N Engl J Med. 1992 May 7;326(19):1250–6. doi: 10.1056/nejm199205073261904. PMID: 1560801.1560801
48 McCleane G. 200 mg daily of lamotrigine has no analgesic effect in neuropathic pain: a randomised, double-blind, placebo controlled trial. Pain. 1999 Oct;83(1):105–7. PMID: 10506679.10506679
49 Raskin P, Donofrio PD, Rosenthal NR, . Topiramate vs placebo in painful diabetic neuropathy: analgesic and metabolic effects. Neurology. 2004 Sep 14;63(5):865–73. PMID: 15365138.15365138
50 Raskin J, Pritchett YL, Wang F, . A double-blind, randomized multicenter trial comparing duloxetine with placebo in the management of diabetic peripheral neuropathic pain. Pain Med. 2005 Sep–Oct;6(5):346–56. 10.1111/j.1526-4637.2005.00061.x. PMID: 16266355.16266355
51 Rauck RL, Shaibani A, Biton V, . Lacosamide in painful diabetic peripheral neuropathy: a phase 2 double-blind placebo-controlled study. Clin J Pain. 2007 Feb;23(2):150–8. doi: 10.1097/01.ajp.0000210957.39621.b2. PMID: 17237664.17237664
52 Richter RW, Portenoy R, Sharma U, . Relief of painful diabetic peripheral neuropathy with pregabalin: a randomized, placebo-controlled trial. J Pain. 2005 Apr;6(4):253–60. doi: 10.1016/j.jpain.2004.12.007. PMID: 15820913.15820913
53 Rosenstock J, Tuchman M, LaMoreaux L, . Pregabalin for the treatment of painful diabetic peripheral neuropathy: a double-blind, placebo-controlled trial. Pain. 2004 Aug;110(3):628–38. doi: 10.1016/j.pain.2004.05.001. PMID: 15288403.15288403
54 Rowbotham MC, Goli V, Kunz NR, . Venlafaxine extended release in the treatment of painful diabetic neuropathy: a double-blind, placebo-controlled study. Pain. 2004 Aug;110(3):697–706. doi: 10.1016/j.pain.2004.05.010. PMID: 15288411.15288411
55 Sang CN, Booher S, Gilron I, . Dextromethorphan and memantine in painful diabetic neuropathy and postherpetic neuralgia: efficacy and dose-response trials. Anesthesiology. 2002 May;96(5):1053–61. PMID: 11981142.11981142
56 Satoh J, Yagihashi S, Baba M, . Efficacy and safety of pregabalin for treating neuropathic pain associated with diabetic peripheral neuropathy: a 14 week, randomized, double-blind, placebo-controlled trial. Diabet Med. 2011 Jan;28(1):109–16. doi: 10.1111/j.1464-5491.2010.03152.x. PMID: 21166852.21166852
57 Scheffler NM, Sheitel PL, Lipton MN. Treatment of painful diabetic neuropathy with capsaicin 0.075%. J Am Podiatr Med Assoc. 1991 Jun;81(6):288–93. doi: 10.7547/87507315-81-6-288. PMID: 1920093.1920093
58 Schwartz S, Etropolski M, Shapiro DY, . Safety and efficacy of tapentadol ER in patients with painful diabetic peripheral neuropathy: results of a randomized-withdrawal, placebo-controlled trial. Curr Med Res Opin. 2011 Jan;27(1):151–62. doi: 10.1185/03007995.2010.537589. PMID: 21162697.21162697
59 Shaibani A, Fares S, Selam JL, . Lacosamide in painful diabetic neuropathy: an 18-week double-blind placebo-controlled trial. J Pain. 2009 Aug;10(8):818–28. doi: 10.1016/j.jpain.2009.01.322. PMID: 19409861.19409861
60 Simpson DA. Gabapentin and venlafaxine for the treatment of painful diabetic neuropathy. J Clin Neuromuscul Dis. 2001 Dec;3(2):53–62. PMID: 19078655.19078655
61 Sindrup SH, Ejlertsen B, Froland A, . Imipramine treatment in diabetic neuropathy: relief of subjective symptoms without changes in peripheral and autonomic nerve function. Eur J Clin Pharmacol. 1989;37(2):151–3. PMID: 2792168.2792168
62 Sindrup SH, Gram LF, Brosen K, . The selective serotonin reuptake inhibitor paroxetine is effective in the treatment of diabetic neuropathy symptoms. Pain. 1990 Aug;42(2):135–44. PMID: 2147235.2147235
63 Tandan R, Lewis GA, Krusinski PB, . Topical capsaicin in painful diabetic neuropathy. Controlled study with long-term follow-up. Diabetes Care. 1992 Jan;15(1):8–14. PMID: 1737545.1737545
64 Thienel U, Neto W, Schwabe SK, . Topiramate in painful diabetic polyneuropathy: findings from three double-blind placebo-controlled trials. Acta Neurol Scand. 2004 Oct;110(4):221–31. doi: 10.1111/j.1600-0404.2004.00338.x. PMID: 15355485.15355485
65 Tolle T, Freynhagen R, Versavel M, . Pregabalin for relief of neuropathic pain associated with diabetic neuropathy: a randomized, double-blind study. Eur J Pain. 2008 Feb;12(2):203–13. doi: 10.1016/j.ejpain.2007.05.003. PMID: 17631400.17631400
66 Vinik AI, Tuchman M, Safirstein B, . Lamotrigine for treatment of pain associated with diabetic neuropathy: results of two randomized, double-blind, placebo-controlled studies. Pain. 2007 Mar;128 1–2:169–79. doi: 10.1016/j.pain.2006.09.040. PMID: 17161535.17161535
67 Vrethem M, Boivie J, Arnqvist H, . A comparison a amitriptyline and maprotiline in the treatment of painful polyneuropathy in diabetics and nondiabetics. Clin J Pain. 1997 Dec;13(4):313–23. PMID: 9430812.9430812
68 Watson CP, Moulin D, Watt-Watson J, . Controlled-release oxycodone relieves neuropathic pain: a randomized controlled trial in painful diabetic neuropathy. Pain. 2003 Sep;105 1–2:71–8. PMID: 14499422.14499422
69 Wernicke JF, Pritchett YL, D’Souza DN, . A randomized controlled trial of duloxetine in diabetic peripheral neuropathic pain. Neurology. 2006 Oct 24;67(8):1411–20. doi: 10.1212/01.wnl.0000240225.04000.1a. PMID: 17060567.17060567
70 Wilton T. Tegretol in the Treatment of Diabetic Neuropathy. SA Mediese Tydskrif. 1974:869–72.
71 Wright JM, Oki JC, Graves L, 3rd. Mexiletine in the symptomatic treatment of diabetic peripheral neuropathy. Ann Pharmacother. 1997 Jan;31(1):29–34. PMID: 8997461.8997461
72 Wymer JP, Simpson J, Sen D, . Efficacy and safety of lacosamide in diabetic neuropathic pain: an 18-week double-blind placebo-controlled trial of fixed-dose regimens. Clin J Pain. 2009 Jun;25(5):376–85. doi: 10.1097/AJP.0b013e318196d2b6. PMID: 19454870.19454870
73 Ziegler D, Hidvegi T, Gurieva I, . Efficacy and safety of lacosamide in painful diabetic neuropathy. Diabetes Care. 2010 Apr;33(4):839–41. doi: 10.2337/dc09-1578. PMID: 20067958.20067958
74 Ziegler D, Low PA, Litchy WJ, . Efficacy and safety of antioxidant treatment with alpha-lipoic acid over 4 years in diabetic polyneuropathy: the NATHAN 1 trial. Diabetes Care. 2011 Sep;34(9):2054–60. doi: 10.2337/dc11-0503. PMID: 21775755.21775755
75 Ziegler D, Ametov A, Barinov A, . Oral treatment with alpha-lipoic acid improves symptomatic diabetic polyneuropathy: the SYDNEY 2 trial. Diabetes Care. 2006 Nov;29(11):2365–70. doi: 10.2337/dc06-1216. PMID: 17065669.17065669
76 Ziegler D, Hanefeld M, Ruhnau KJ, . Treatment of symptomatic diabetic polyneuropathy with the antioxidant α-lipoic acid: A 7-month multicenter randomized controlled trial (ALADIN III study). Diabetes Care. 1999;22(8):1296–301.10480774
77 Ziegler D, Hanefeld M, Ruhnau KJ, . Treatment of symptomatic diabetic peripheral neuropathy with alpha-lipoic acid. A 3-week multicentre randomized controlled trial (ALADIN Study. Diabetes Und Stoffwechsel. 1996;5(3 suppl.):102–10.
78 Ametov AS, Barinov A, Dyck PJ, . The sensory symptoms of diabetic polyneuropathy are improved with alpha-lipoic acid: the SYDNEY trial. Diabetes Care. 2003 Mar;26(3):770–6. PMID: 12610036.12610036
79 Ruhnau KJ, Meissner HP, Finn JR, . Effects of 3-week oral treatment with the antioxidant thioctic acid (alpha-lipoic acid) in symptomatic diabetic polyneuropathy. Diabet Med. 1999 Dec;16(12):1040–3. PMID: 10656234.10656234
80 De Grandis D, Minardi C. Acetyl-L-carnitine (levacecarnine) in the treatment of diabetic neuropathy. A long-term, randomised, double-blind, placebo-controlled study. Drugs R D. 2002;3(4):223–31. PMID: 12455197.12455197
81 Garrow AP, Xing M, Vere J, . Role of acupuncture in the management of diabetic painful neuropathy (DPN): a pilot RCT. Acupunct Med. 2014 Jun;32(3):242–9. doi: 10.1136/acupmed-2013-010495. PMID: 24657491.24657491
82 Otis JD, Sanderson K, Hardway C, . A randomized controlled pilot study of a cognitive-behavioral therapy approach for painful diabetic peripheral neuropathy. J Pain. 2013 May;14(5):475–82. doi: 10.1016/j.jpain.2012.12.013. PMID: 23452825.23452825
83 Lacigova S, Tomesova J, Gruberova J, . “Mesodiencephalic” modulation in the treatment of diabetic neuropathy. Neuro Endocrinol Lett. 2013;34(2):135–42. PMID: 23645311.23645311
84 Gossrau G, Wahner M, Kuschke M, . Microcurrent transcutaneous electric nerve stimulation in painful diabetic neuropathy: a randomized placebo-controlled study. Pain Med. 2011 Jun;12(6):953–60. doi: 10.1111/j.1526-4637.2011.01140.x. PMID: 21627767.21627767
85 Forst T, Nguyen M, Forst S, . Impact of low frequency transcutaneous electrical nerve stimulation on symptomatic diabetic neuropathy using the new Salutaris device. Diabetes Nutr Metab. 2004 Jun;17(3):163–8. PMID: 15334794.15334794
86 Hamza MA, White PF, Craig WF, . Percutaneous electrical nerve stimulation: a novel analgesic therapy for diabetic neuropathic pain. Diabetes Care. 2000 Mar;23(3):365–70. PMID: 10868867.10868867
87 Oyibo SO, Breislin K, Boulton AJ. Electrical stimulation therapy through stocking electrodes for painful diabetic neuropathy: a double blind, controlled crossover study. Diabet Med. 2004 Aug;21(8):940–4. doi: 10.1111/j.1464-5491.2004.01243.x. PMID: 15270803.15270803
88 Kumar D, Alvaro MS, Julka IS, . Diabetic peripheral neuropathy. Effectiveness of electrotherapy and amitriptyline for symptomatic relief. Diabetes Care. 1998 Aug;21(8):1322–5. PMID: 9702441.9702441
89 Kumar D, Marshall HJ. Diabetic peripheral neuropathy: amelioration of pain with transcutaneous electrostimulation. Diabetes Care. 1997 Nov;20(11):1702–5. PMID: 9353612.9353612
90 Bosi E, Bax G, Scionti L, . Frequency-modulated electromagnetic neural stimulation (FREMS) as a treatment for symptomatic diabetic neuropathy: results from a double-blind, randomised, multicentre, long-term, placebo-controlled clinical trial. Diabetologia. 2013 Mar;56(3):467–75. doi: 10.1007/s00125-012-2795-7. PMID: 23238789.23238789
91 Bosi E, Conti M, Vermigli C, . Effectiveness of frequency-modulated electromagnetic neural stimulation in the treatment of painful diabetic neuropathy. Diabetologia. 2005 May;48(5):817–23. doi: 10.1007/s00125-005-1734-2. PMID: 15834546.15834546
92 Onesti E, Gabriele M, Cambieri C, . H-coil repetitive transcranial magnetic stimulation for pain relief in patients with diabetic neuropathy. European Journal of Pain (United Kingdom). 2013;17(9):1347–56.
93 Weintraub MI, Herrmann DN, Smith AG, . Pulsed Electromagnetic Fields to Reduce Diabetic Neuropathic Pain and Stimulate Neuronal Repair: A Randomized Controlled Trial. Arch Phys Med Rehabil. 2009;90(7):1102–9.19577022
94 Macare van Maurik JF, Oomen RT, van Hal M, . The effect of lower extremity nerve decompression on health-related quality of life and perception of pain in patients with painful diabetic polyneuropathy: a prospective randomized trial. Diabet Med. 2015 Jun;32(6):803–9. doi: 10.1111/dme.12732. PMID: 25712758.25712758
95 Macare van Maurik JF, van Hal M, van Eijk RP, . Value of surgical decompression of compressed nerves in the lower extremity in patients with painful diabetic neuropathy: a randomized controlled trial. Plast Reconstr Surg. 2014 Aug;134(2):325–32. doi: 10.1097/prs.0000000000000369. PMID: 24732651.24732651
96 de Vos CC, Meier K, Zaalberg PB, . Spinal cord stimulation in patients with painful diabetic neuropathy: a multicentre randomized clinical trial. Pain. 2014 Nov;155(11):2426–31. doi: 10.1016/j.pain.2014.08.031. PMID: 25180016.25180016
97 Slangen R, Schaper NC, Faber CG, . Spinal cord stimulation and pain relief in painful diabetic peripheral neuropathy: a prospective two-center randomized controlled trial. Diabetes Care. 2014 Nov;37(11):3016–24. doi: 10.2337/dc14-0684. PMID: 25216508.25216508