# Appendix C Excluded Articles

## KQ1 Excluded Articles

### No full report/original data

Induration of the diabetic foot pad: another risk factor for recurrent neuropathic plantar ulcers. T. Brink. Biomed Tech (Berl) 1995: 205–9 7548685
Effect of near normoglycaemia for two years on progression of early diabetic retinopathy, nephropathy, and neuropathy: the Oslo study. K. Dahl-Jorgensen, O. Brinchmann-Hansen, K. F. Hanssen, T. Ganes, P. Kierulf, E. Smeland, L. Sandvik, O. Aagenaes. Br Med J (Clin Res Ed) 1986: 1195–9
Metformin, methylmalonic acid and the risk of neuropathy: A randomised placebo-controlled trial. M. Out, A. Kooy, P. Lehert, C. G. Schalkwijk, C. D. A. Stehouwer. Diabetologia 2015: S110–S111
Capsaicin 8% patch repeat treatment versus standard of care in painful diabetic peripheral neuropathy: A randomised, open-label, 52-week study. A. I. Vinik, S. Perrot, E. J. Vinik, L. Pazdera, H. Jacobs, M. Stoker, S. Long, R. Snijder, M. Van Der Stoep, E. Ortega, N. Katz. Diabetologia 2015: S514–S515
Incidence of microvascular outcomes in type 2 diabetes patients treated with vildagliptin vs sulphonylurea: A retrospective study using German electronic medical records. W. M. Kolaczynski, M. Hankins, S. H. Ong, H. Richter, A. Clemens, M. Toussi. Diabetologia 2015: S394
Pregabalin positively affects subjective pain, falls risk, and gait in persons with diabetic peripheral neuropathy. S. Morrison, H. Parson, A. I. Vinik. Diabetes 2015: A164
Incidence of microvascular outcomes among type 2 diabetes patients treated with vildagliptin vs. Sulfonylurea: A retrospective cohort study using german electronic medical records. M. Hankins, S. H. Ong, H. Richter, W. M. Kolaczynski, A. Clemens, G. Machnicki, M. Toussi, J. Vora. Diabetes 2015: A4
Effect of intensive weight reduction on neuropathy progression in patients with diabetes: A 1-year controlled clinical trial. A. Mottalib, A. Morsi, M. Shehabeldin, M. Sakr, O. Hamdy. Diabetes 2015: A51–A52
The effects of treatment modalities on outcome in diabetic foot patients and retrospective evaluation of comorbidities. E. Ozay, O. Ersen, S. Bilgic, O. Rodop. European Surgical Research 2015: 163
Incidence and impact of hypoglycemia in diabetic patients with intensified glycaemic control in clinical practice-results of DiaRegis. A. K. Gitt, P. Bramlage, S. Schneider, C. Binz, M. Krekler, D. Tschoepe. European Heart Journal 2014: 1020–1021
Regular exercise improves metabolic control and reduces chronic complications in patients with type 2 diabetes. J. Tang, X. Li, Y. Yang, L. Yuan, J. Han, C. Ju, L. Shen, Q. Lou, F. Zhao, Z. Sun, X. Guo. Diabetologia 2014: S434
Game-based guided exercise: Using an avatar with real-time feed back to improve postural stability in diabetic peripheral neuro pathy. B. Najafi, G. Grewal, J. Lee-Eng, T. K. Talal, R. A. Menzies, D. G. Armstrong. Diabetes 2014: A186
Effect of roux-en-y gastric bypass surgery on microvascular complications of type 2 diabetes mellitus. L. L. Chuah, A. D. Miras, D. Papamargaritis, A. Vusiri Kala, S. N. Jackson, N. Oliver, T. Olbers, C. W. Le Roux. Diabetes 2014: A525
Nutrition intervention for diabetic neuropathy. A. E. Bunner, J. Gonzalez, U. Agarwal, F. Valente, N. D. Barnard. Diabetes 2014: A578
The effects of treatment modalities on outcome in diabetic foot patients. E. Ozay, S. Bilgic, O. Rodop, O. Ersen. European Surgical Research 2014: 241
Helping patient with diabetes through physical activity. S. Zeqiri, N. Zeqiri, A. Ylli. Annals of Physical and Rehabilitation Medicine 2014: e323–e324
Complex neurorehabilitation programme improves quality of life of patients with diabetic polyneuropathy and diabetic foot. Y. Koleva. Annals of Physical and Rehabilitation Medicine 2013: e38–e39
Determination of the the effectiveness of home exercise program in patients with diabetic neuropathy. L. L. Cerrahotlu, U. Kosan, E. Topcu. Turkiye Fiziksel Tip ve Rehabilitasyon Dergisi 2013: 359
Efficacy of weight reduction program on obese patients with diabetic peripheral neuropathy. G. M. Ahmed, M. M. Mostafa, M. F. Farouk, A. E. G. El Gohary. Diabetes Technology and Therapeutics 2013: A123
Initial vascular response to clear cleat cycling in patients at risk for dfu. R. T. Crews, S. R. Smith, S. B. Liu. Diabetes 2012: A165–A166
Impact of one-year smoking cessation upon type 2 diabetes diagnosis. C. Voulgari, N. Tentolouris, K. Makrilakis, N. Papanas, C. Manes, N. Katsilambros. Diabetes 2011: A227–A228
Relationship between foot range of movement and plantar pressure distribution in diabetic neuropathic patients. C. D. Sartor, A. P. Picon, M. I. Roveri, R. C. Dinato, I. C. N. Sacco. Clinical Biomechanics 2011: 674
Gait, balance and plantar temperature fluctuation in charcot and diabetes patients with and without active foot ulcer. B. Najafi, G. S. Grewal, R. A. Menzies, T. K. Talal, M. A. Zirie, D. G. Armstrong. Diabetes 2011: A18
Smart prevention device for foot infection. M. Rocklinger, P. Vacherand, F. Brönnimann, A. Mathieu, A. Stéphane, Z. Pataky. BMC Proceedings 2011:
Patient-reported outcomes in subjects with painful diabetic peripheral neuropathy: Pain description and quality of life. K. S. Ko, B. Y. Cha, C. H. Kim, H. S. Kwon, J. H. Lee, T. S. Park, J. C. Won, S. K. Ko, H. J. Park. Value in Health 2011: A66
Exploring postural compensation in diabetes-related neuropathy patients (DPN): The role of visual and somatosensory adaptation. B. Najafi, R. T. Crews, S. C. Wu, J. S. Wrobel. Diabetes 2010:
The toe-to-forefoot plantar pressure ratio is increased in severe diabetic neuropathy. Y. Fujioka, S. I. Taniguchi, H. Kinoshita, K. Sumi, H. Shiochi, N. Yamamoto, K. Matsuzawa, S. Izawa, T. Ohkura, H. Ohkura, C. Shigemasa. Diabetes 2010:
Game-based system for evaluation of balance control in diabetic sensory neuropathy. B. Najafi, S. Wu, N. S. Rivera, R. Crews, D. G. Armstrong, J. Wrobel. Diabetes 2009:
Effects of a combined strengthening, stretching and functional training program versus usual-care on gait biomechanics and foot function for diabetic neuropathy: a randomized controlled trial. C. D. Sartor, R. Watari, A. C. Pássaro, A. P. Picon, R. H. Hasue, I. C. Sacco. BMC Musculoskelet Disord 2012: 36 22429765
Determination of the the effectiveness of home exercise program in patients with diabetic neuropathy, Diyabetik Noropatili Hastalarda Ev Egzersiz Programinin Etkinlitinin Belirlenmesi. [Turkish, English]. L. Cerrahotlu, U. Kosan, E. Topcu. Turkiye Fiziksel Tip ve Rehabilitasyon Dergisi 2013: 359
Effects of exenatide on measures of small fiber neuropathy in patients with type 2 diabetes. M. Jaiswal, C. L. Martin, R. Pop Busui. Diabetes 2014: A149
A pilot study of intranasal insulin for the treatment of diabetic peripheral neuropathy. L. Korngut, S. Mawani, G. Francis, E. Mehina, B. Hemmelgarn, N. Jette, D. W. Zochodne, S. Wiebe, C. Toth. Journal of the Peripheral Nervous System 2013: S59
Effect of ruboxistaurin on albuminuria and estimated GFR in people with diabetic peripheral neuropathy: Results from a randomized trial. K. R. Tuttle, J. B. McGill, E. J. Bastyr, K. K. Poi, N. Shahri, P. W. Anderson. American Journal of Kidney Diseases 2015: 634–6 25618186
A multidisciplinary approach is effective in decreasing major lower extremity amputations. V. Provenzano, L. Ferrara, D. Brancato, A. Scorsone, V. Aiello, A. Di Noto, M. Fleres, F. Provenzano, G. Saura, L. Spano. Italian Journal of Medicine 2015: 88
Empowering and improving foot care in type 2 diabetic patients referred to diabetes clinic of semirom city isfahan province Iran:2012–2013 application of basnef model. M. Taghdisi, M. Afshari, K. Azam, A. Z. A. R. Tol. Diabetes Technology and Therapeutics 2015: A133
Hospitalizations and patient outcomes between a pharmacistphysician diabetes co-management service and usual care. A. Airee, A. W. Dake, P. Mahbubani, J. D. Williams, R. E. Heidel. Pharmacotherapy 2014: e234
Randomized double blind clinical trial: Utilization of umbilical cord blood-derived platelet gel for treatment of diabetic foot ulcers. E. S. Hosseini, A. Goodarzi, B. Molavi, N. Aghdami. Cell Journal 2014: 46–47
Control of lower extremity edema in patients with diabetes: Double-blind RCT assessing the efficacy of mild compression diabetic socks. S. C. Wu, R. T. Crews, M. Skratsky, M. Branigan, J. Ortiz, C. Andersen. Diabetes 2015: A37
Effect of intensive weight reduction on neuropathy progression in patients with diabetes: A 1-year controlled clinical trial. A. Mottalib, A. Morsi, M. Shehabeldin, M. Sakr, O. Hamdy. Diabetes 2015: A51–a52
Supervised structured exercise training for people with diabetic peripheral neuropathy: A randomised control trial. M. Kingsley, B. Perrin, J. Southon, J. McCaig, I. Skinner, T. Skinner. Journal of Science and Medicine in Sport 2015: e95
Reduction of complications and associated costs for type 2 diabetic patients using continuous subcutaneous insulin infusion in the UK. S. Roze, E. Duteil, N. Hallas, S. De Portu. Value in Health 2015: A360
Implementation of foot thermometry plus mHealth to prevent diabetic foot ulcers: study protocol for a randomized controlled trial. M. Lazo-Porras, A. Bernabe-Ortiz, K. A. Sacksteder, R. H. Gilman, G. Malaga, D. G. Armstrong, J. J. Miranda. Trials 2016: 206 27094007
Effect of Patient-Education on Health-Related Quality of Life of Diabetic Foot Ulcer Patients In A Tertiarycare Hospital. S. S. Miraj, R. T. Roy, M. Unnikrishnan, V. K., G. S. Rodrigues, C. Mukhopadhyay. Value Health 2015: A621
A Randomized Controlled Trial Comparing Telemedical and Standard Outpatient Monitoring of Diabetic Foot Ulcers. Diabetes Care 2015;38:1723–1729. 26116717 M. Muller, S. David-Tchouda, J. Margier, M. Oreglia, P. Y. Benhamou. Diabetes Care 2016: e9–e10 26696670
A Randomized Controlled Trial Comparing Telemedical and Standard Outpatient Monitoring of Diabetic Foot Ulcers. Diabetes Care 2015;38:1723–1729. 26116717 K. B. Yderstraede, J. Froekjaer, B. S. B. Rasmussen. Diabetes Care 2016: e11 26696660
Evaluate the effectiveness of a dedicated diabetes specialist nurse in a joint podiatry setting over a 6 month period to compare pre and post biometric data. G. Taft, B. Huda. Diabetic Medicine 2016: 184 26234919

### Not relevant to Key question

Topically Applied Vancomycin Powder Reduces the Rate of Surgical Site Infection in Diabetic Patients Undergoing Foot and Ankle Surgery. D. K. Wukich, J. W. Dikis, S. J. Monaco, K. Strannigan, N. C. Suder, B. L. Rosario. Foot Ankle Int 2015: 1017–24 25967254
Diabetic foot complications and their risk factors from a large retrospective cohort study. K. Al-Rubeaan, M. Al Derwish, S. Ouizi, A. M. Youssef, S. N. Subhani, H. M. Ibrahim, B. N. Alamri. PLoS One 2015: e0124446 25946144
A cohort study of diabetic patients and diabetic foot ulceration patients in China. Y. Jiang, X. Wang, L. Xia, X. Fu, Z. Xu, X. Ran, L. Yan, Q. Li, Z. Mo, Z. Yan, Q. Ji, Q. Li. Wound Repair Regen 2015: 222–30 25682850
Relationship between glycemic control, microalbuminuria and cognitive functions in elderly type 2 diabetic patients. C. B. Gul, O. Oz Gul, S. Cander, A. Eroglu, M. Hartavi, N. Keni, A. Bayindir, C. Ersoy, E. Erturk, E. Tuncel, S. Imamoglu. Ren Fail 2014: 1258–62 25020185
Effect of oral nutritional supplementation on wound healing in diabetic foot ulcers: a prospective randomized controlled trial. D. G. Armstrong, J. R. Hanft, V. R. Driver, A. P. Smith, J. L. Lazaro-Martinez, A. M. Reyzelman, G. J. Furst, D. J. Vayser, H. L. Cervantes, R. J. Snyder, M. F. Moore, P. E. May, J. L. Nelson, G. E. Baggs, A. C. Voss and G. Diabetic Foot Nutrition Study. Diabet Med 2014: 1069–77 24867069
The role of insulin resistance in diabetic neuropathy in Koreans with type 2 diabetes mellitus: a 6-year follow-up study. Y. N. Cho, K. O. Lee, J. Jeong, H. J. Park, S. M. Kim, H. Y. Shin, J. M. Hong, C. W. Ahn, Y. C. Choi. Yonsei Med J 2014: 700–8 24719137
Determination of efficacy of reflexology in managing patients with diabetic neuropathy: a randomized controlled clinical trial. K. Dalal, V. B. Maran, R. M. Pandey, M. Tripathi. Evid Based Complement Alternat Med 2014: 843036 24527055
Current glycemic status and diabetes related complications among type 2 diabetes patients in India: data from the A1chieve study. V. Mohan, S. Shah, B. Saboo. J Assoc Physicians India 2013: 12–5
Effect of glycemic treatment and microvascular complications on menopause in women with type 1 diabetes in the Diabetes Control and Complications Trial/Epidemiology of Diabetes Interventions and Complications (DCCT/EDIC) cohort. C. Kim, P. A. Cleary, C. C. Cowie, B. H. Braffett, R. L. Dunn, M. E. Larkin, P. M. Gatcomb, H. B. Wessells, D. M. Nathan, A. V. Sarma and D. E. R. Group. Diabetes Care 2014: 701–8 24170751
Strength training affects lower extremity gait kinematics, not kinetics, in people with diabetic polyneuropathy. T. Melai, N. C. Schaper, I. J. TH, P. J. Willems, T. L. de Lange, K. Meijer, A. G. Lieverse, H. H. Savelberg. J Appl Biomech 2014: 221–30 24042012
Effects of the endpoint adjudication process on the results of a randomised controlled trial: the ADVANCE trial. J. Hata, H. Arima, S. Zoungas, G. Fulcher, C. Pollock, M. Adams, J. Watson, R. Joshi, A. P. Kengne, T. Ninomiya, C. Anderson, M. Woodward, A. Patel, G. Mancia, N. Poulter, S. MacMahon, J. Chalmers, B. Neal and A. C. Group. PLoS One 2013: e55807 23390553
Mortality and other important diabetes-related outcomes with insulin vs other antihyperglycemic therapies in type 2 diabetes. C. J. Currie, C. D. Poole, M. Evans, J. R. Peters, C. L. Morgan. J Clin Endocrinol Metab 2013: 668–77 23372169
Lower incidence of recorded cardiovascular outcomes in patients with type 2 diabetes using insulin aspart vs. those on human regular insulin: observational evidence from general practices. W. Rathmann, K. Kostev. Diabetes Obes Metab 2013: 358–63 23137345
Identifying the incidence of and risk factors for reamputation among patients who underwent foot amputation. Y. Kono, R. R. Muder. Ann Vasc Surg 2012: 1120–6 22840342
Effect of selected exercises on in-shoe plantar pressures in people with diabetes and peripheral neuropathy. K. M. Shah, M. J. Mueller. Foot (Edinb) 2012: 130–4 22677098
Selection of an above or below-ankle orthosis for individuals with neuropathic partial foot amputation: a pilot study. S. E. Spaulding, T. Chen, L. S. Chou. Prosthet Orthot Int 2012: 217–24 22402710
Functional balance in elderly with diabetic neuropathy. T. Ghanavati, M. J. Shaterzadeh Yazdi, S. Goharpey, A. A. Arastoo. Diabetes Res Clin Pract 2012: 24–8
A multidisciplinary diabetic foot ulcer treatment programme significantly improved the outcome in patients with infected diabetic foot ulcers. C. C. Chiu, C. L. Huang, S. F. Weng, L. M. Sun, Y. L. Chang, F. C. Tsai. J Plast Reconstr Aesthet Surg 2011: 867–72 21216682
Long-term effects of a randomised trial of a 6-year lifestyle intervention in impaired glucose tolerance on diabetes-related microvascular complications: the China Da Qing Diabetes Prevention Outcome Study. Q. Gong, E. W. Gregg, J. Wang, Y. An, P. Zhang, W. Yang, H. Li, H. Li, Y. Jiang, Y. Shuai, B. Zhang, J. Zhang, R. B. Gerzoff, G. Roglic, Y. Hu, G. Li, P. H. Bennett. Diabetologia 2011: 300–7 21046360
Stratified analyses for selecting appropriate target patients with diabetic peripheral neuropathy for long-term treatment with an aldose reductase inhibitor, epalrestat. N. Hotta, R. Kawamori, Y. Atsumi, M. Baba, H. Kishikawa, J. Nakamura, S. Oikawa, N. Yamada, H. Yasuda, Y. Shigeta and A. S. Group. Diabet Med 2008: 818–25 18644069
Effect of Achilles tendon lengthening on neuropathic plantar ulcers. A randomized clinical trial. M. J. Mueller, D. R. Sinacore, M. K. Hastings, M. J. Strube, J. E. Johnson. J Bone Joint Surg Am 2003: 1436–45 12925622
Static magnetic field therapy for symptomatic diabetic neuropathy: a randomized, double-blind, placebo-controlled trial. M. I. Weintraub, G. I. Wolfe, R. A. Barohn, S. P. Cole, G. J. Parry, G. Hayat, J. A. Cohen, J. C. Page, M. B. Bromberg, S. L. Schwartz and G. Magnetic Research. Arch Phys Med Rehabil 2003: 736–46 12736891
Effect of Yoga asanas on nerve conduction in type 2 diabetes. V. Malhotra, S. Singh, O. P. Tandon, S. V. Madhu, A. Prasad, S. B. Sharma. Indian J Physiol Pharmacol 2002: 298–306 12613392
Diabetes education and care management significantly improve patient outcomes in the dialysis unit. S. D. McMurray, G. Johnson, S. Davis, K. McDougall. Am J Kidney Dis 2002: 566–75 12200809
Off-loading the diabetic foot wound: a randomized clinical trial. D. G. Armstrong, H. C. Nguyen, L. A. Lavery, C. H. van Schie, A. J. Boulton, L. B. Harkless. Diabetes Care 2001: 1019–22 11375363
Timing of peak plantar pressure during the stance phase of walking. A study of patients with diabetes mellitus and transmetatarsal amputation. V. E. Kelly, M. J. Mueller, D. R. Sinacore. J Am Podiatr Med Assoc 2000: 18–23 10659528
The use of dynamic posturography to detect neurosensorial disorder in IDDM without clinical neuropathy. W. Di Nardo, G. Ghirlanda, S. Cercone, D. Pitocco, C. Soponara, A. Cosenza, G. Paludetti, M. A. Di Leo, I. Galli. J Diabetes Complications 1999: 79–85 10432171
An analysis of dynamic forces transmitted through the foot in diabetic neuropathy. J. E. Shaw, C. H. van Schie, A. L. Carrington, C. A. Abbott, A. J. Boulton. Diabetes Care 1998: 1955–9 9802750
Is there a critical level of plantar foot pressure to identify patients at risk for neuropathic foot ulceration?. D. G. Armstrong, E. J. Peters, K. A. Athanasiou, L. A. Lavery. J Foot Ankle Surg 1998: 303–7 9710782
Aerobic exercise capacity remains normal despite impaired endothelial function in the micro- and macrocirculation of physically active IDDM patients. A. Veves, R. Saouaf, V. M. Donaghue, C. A. Mullooly, J. A. Kistler, J. M. Giurini, E. S. Horton, R. A. Fielding. Diabetes 1997: 1846–52 9356035
Intensive therapy in adult insulin-dependent diabetes mellitus is associated with improved insulin sensitivity and reserve: a randomized, controlled, prospective study over 5 years in newly diagnosed patients. T. Linn, K. Ortac, H. Laube, K. Federlin. Metabolism 1996: 1508–13 8969284
The prevalence of neuropathic foot ulceration in Sri Lankan diabetic patients. D. J. Fernando. Ceylon Med J 1996: 96–8 8917968
Postural rearrangement in IDDM patients with peripheral neuropathy. P. G. Giacomini, E. Bruno, G. Monticone, S. Di Girolamo, A. Magrini, L. Parisi, G. Menzinger, L. Uccioli. Diabetes Care 1996: 372–4 8729163
Induration of the diabetic foot pad: another risk factor for recurrent neuropathic plantar ulcers. T. Brink. Biomed Tech (Berl) 1995: 205–9 7548685
The effect of intensive diabetes therapy on the development and progression of neuropathy. The Diabetes Control and Complications Trial Research Group. . Ann Intern Med 1995: 561–8
The effect of intensive treatment of diabetes on the development and progression of long-term complications in insulin-dependent diabetes mellitus. The Diabetes Control and Complications Trial Research Group. . N Engl J Med 1993: 977–86 8366922
Differential effects of near-normoglycaemia for 4 years on somatic nerve dysfunction and heart rate variation in type 1 diabetic patients. D. Ziegler, K. Dannehl, K. Wiefels, F. A. Gries. Diabet Med 1992: 622–9 1511568
Problems with gait and posture in neuropathic patients with insulin-dependent diabetes mellitus. P. R. Cavanagh, J. A. Derr, J. S. Ulbrecht, R. E. Maser, T. J. Orchard. Diabet Med 1992: 469–74 1611836
Effect of near normoglycaemia for two years on progression of early diabetic retinopathy, nephropathy, and neuropathy: the Oslo study. K. Dahl-Jorgensen, O. Brinchmann-Hansen, K. F. Hanssen, T. Ganes, P. Kierulf, E. Smeland, L. Sandvik, O. Aagenaes. Br Med J (Clin Res Ed) 1986: 1195–9
Early treatment of diabetic neuropathy. X. L. Zhong, B. D. Zheng, G. X. Hu, X. X. Zhu, Z. M. Hu. Chin Med J (Engl) 1981: 503–8 6791891
Incidence of microvascular outcomes among type 2 diabetes patients treated with vildagliptin vs. Sulfonylurea: A retrospective cohort study using german electronic medical records. M. Hankins, S. H. Ong, H. Richter, W. M. Kolaczynski, A. Clemens, G. Machnicki, M. Toussi, J. Vora. Diabetes 2015: A4
Effect of intensive weight reduction on neuropathy progression in patients with diabetes: A 1-year controlled clinical trial. A. Mottalib, A. Morsi, M. Shehabeldin, M. Sakr, O. Hamdy. Diabetes 2015: A51–A52
Relationship between β-cell function, metabolic control, and microvascular complications in type 2 diabetes mellitus. L. Zhao, J. Ma, S. Wang, Y. Xie. Diabetes Technology and Therapeutics 2015: 29–34
Gender based disparities in ACE I/D polymorphism associated with progression of diabetic nephropathy in Pakistani patients with type 2 diabetes mellitus. Q. Mansoor, N. Bilal, S. Qureshi, O. Qureshi, A. Javaid, M. Ismail. International Journal of Diabetes and Metabolism 2010: 67–71
Fractures in the neuropathic diabetic foot. J. Sinha, E. M. Thomas, A. Foster, M. Edmonds. Foot 1994: 28–30
Preventing diabetic foot ulcer recurrence in high-risk patients: use of temperature monitoring as a self-assessment tool. L. A. Lavery, K. R. Higgins, D. R. Lanctot, G. P. Constantinides, R. G. Zamorano, K. A. Athanasiou, D. G. Armstrong, C. M. Agrawal. Diabetes Care 2007: 14–20 17192326
Effects of strengthening, stretching and functional training on foot function in patients with diabetic neuropathy: results of a randomized controlled trial. I. C. Sacco, R. H. Hasue, L. P. Cacciari, M. K. Butugan, R. Watari, A. C. Passaro, C. Giacomozzi. BMC Musculoskelet Disord 2014: 137 24767584
The use of PriMatrix, a fetal bovine acellular dermal matrix, in healing chronic diabetic foot ulcers: a prospective multicenter study. S. J. Kavros, T. Dutra, R. Gonzalez-Cruz, B. Liden, B. Marcus, J. McGuire, L. Nazario-Guirau. Adv Skin Wound Care 2014: 356–62 25033310
Randomised controlled clinical trial for autologous fibroblast-hyaluronic acid complex in treating diabetic foot ulcers. H. J. You, S. K. Han, J. W. Rhie. J Wound Care 2014: 521–2, 524, 526–30
Prevention of recurrent foot ulcers with plantar pressure-based in-shoe orthoses: the CareFUL prevention multicenter randomized controlled trial. J. S. Ulbrecht, T. Hurley, D. T. Mauger, P. R. Cavanagh. Diabetes Care 2014: 1982–9 24760263
Self-efficacy in foot-care and effect of training: a single-blinded randomized controlled clinical trial. A. Seyyedrasooli, K. Parvan, L. Valizadeh, A. Rahmani, M. Zare, T. Izadi. Int J Community Based Nurs Midwifery 2015: 141–9 26005694
A pilot study evaluating non-contact low-frequency ultrasound and underlying molecular mechanism on diabetic foot ulcers. M. Yao, H. Hasturk, A. Kantarci, G. Gu, S. Garcia-Lavin, M. Fabbi, N. Park, H. Hayashi, K. Attala, M. A. French, V. R. Driver. Int Wound J 2014: 586–593 23163982
Effects of strengthening, stretching and functional training on foot function in patients with diabetic neuropathy: Results of a randomized controlled trial. C. D. Sartor, R. H. Hasue, L. P. Cacciari, M. K. Butugan, R. Watari, A. C. Pássaro, C. Giacomozzi, I. C. Sacco. BMC Musculoskelet Disord 2014:
Effects of strengthening, stretching and functional training on foot function in patients with diabetic neuropathy: Results of a randomized controlled trial. C. D. Sartor, R. H. Hasue, L. P. Cacciari, M. K. Butugan, R. Watari, A. C. Pássaro, C. Giacomozzi, I. C. N. Sacco. BMC Musculoskelet Disord 2014:
Strength training affects lower extremity gait kinematics, not kinetics, in people with diabetic polyneuropathy. T. Melai, N. C. Schaper, I. J. TH, P. J. B. Willems, T. L. H. De Lange, K. Meijer, A. G. Lieverse, H. H. C. M. Savelberg. J Appl Biomech 2014: 221–230 24042012
Magnetic resonance neurography detects diabetic neuropathy early and with Proximal Predominance. M. Pham, D. Oikonomou, B. Hornung, M. Weiler, S. Heiland, P. Baumer, J. Kollmer, P. P. Nawroth, M. Bendszus. Ann Neurol 2015: 939–48 26381658

### Not evaluating people with type 1 or type 2 diabetes with peripheral polyneuropathy

Influence of remission and its duration on development of early microvascular complications in young adults with type 1 diabetes. P. Niedzwiecki, S. Pilacinski, A. Uruska, A. Adamska, D. Naskret, D. Zozulinska-Ziolkiewicz. J Diabetes Complications 2015:
Near-normoglycaemia and development of neuropathy: a 24-year prospective study from diagnosis of type 1 diabetes. D. Ziegler, M. Behler, M. Schroers-Teuber, M. Roden. BMJ Open 2015: e006559
Management trajectories in the type 2 diabetes Integrated Delivery System project in Taiwan: accounting for behavioral therapy, nutrition education and therapeutics. H. Y. Chang, M. L. Wahlqvist, W. L. Liu, M. S. Lee, S. J. Shin, Y. S. Li, C. J. Chang, C. T. Chang, M. T. Fuh, H. J. Yang, T. Y. Tai, C. C. Hsu. Asia Pac J Clin Nutr 2014: 592–606 25516317
Completion report: Effect of Comprehensive Yogic Breathing program on type 2 diabetes: A randomized control trial. V. P. Jyotsna, A. Dhawan, V. Sreenivas, K. K. Deepak, R. Singla. Indian J Endocrinol Metab 2014: 582–4 25143922
Continuous subcutaneous insulin infusion preserves axonal function in type 1 diabetes mellitus. N. Kwai, R. Arnold, A. M. Poynten, C. S. Lin, M. C. Kiernan, A. V. Krishnan. Diabetes Metab Res Rev 2015: 175–82 25066412
Severity of demographic and clinical characteristics, revascularization feasibility, major amputation, and mortality rate in diabetic patients admitted to a tertiary diabetic foot center for critical limb ischemia: comparison of 2 cohorts recruited at a 10-year distance. E. Faglia, G. Clerici, A. Scatena, M. Caminiti, V. Curci, M. Prisco, V. Prisco, R. Greco, F. Cetta, A. Morabito. Ann Vasc Surg 2014: 1729–36 24952297
Exercise improves gait, reaction time and postural stability in older adults with type 2 diabetes and neuropathy. S. Morrison, S. R. Colberg, H. K. Parson, A. I. Vinik. J Diabetes Complications 2014: 715–22 24929798
Effect of oral nutritional supplementation on wound healing in diabetic foot ulcers: a prospective randomized controlled trial. D. G. Armstrong, J. R. Hanft, V. R. Driver, A. P. Smith, J. L. Lazaro-Martinez, A. M. Reyzelman, G. J. Furst, D. J. Vayser, H. L. Cervantes, R. J. Snyder, M. F. Moore, P. E. May, J. L. Nelson, G. E. Baggs, A. C. Voss and G. Diabetic Foot Nutrition Study. Diabet Med 2014: 1069–77 24867069
Long-term effects of goshajinkigan in prevention of diabetic complications: a randomized open-labeled clinical trial. K. Watanabe, A. Shimada, K. Miyaki, A. Hirakata, K. Matsuoka, K. Omae, I. Takei. Evid Based Complement Alternat Med 2014: 128726 24812564
Obese patients with diabetes mellitus type 2 undergoing gastric bypass in Roux-en-Y: analysis of results and its influence in complications. J. L. Zeve, C. A. Tomaz, P. A. Nassif, J. H. Lima, L. R. Sansana, C. H. Zeve. Arq Bras Cir Dig 2013: 47–52 24463899
Neuropathy and related findings in the diabetes control and complications trial/epidemiology of diabetes interventions and complications study. C. L. Martin, J. W. Albers, R. Pop-Busui and D. E. R. Group. Diabetes Care 2014: 31–8 24356595
Area-under-the-HbA1c-curve above the normal range and the prediction of microvascular outcomes: an analysis of data from the Diabetes Control and Complications Trial. L. J. Maple-Brown, C. Ye, R. Retnakaran. Diabet Med 2013: 95–9 22937915
Identifying the incidence of and risk factors for reamputation among patients who underwent foot amputation. Y. Kono, R. R. Muder. Ann Vasc Surg 2012: 1120–6 22840342
Micro- and macrovascular outcomes in Type 2 diabetic patients treated with insulin glulisine or human regular insulin: a retrospective database analysis. S. Kress, K. Kostev, F. W. Dippel, G. Giani, W. Rathmann. Int J Clin Pharmacol Ther 2012: 821–9 22578200
Effects of manidipine and delapril in hypertensive patients with type 2 diabetes mellitus: the delapril and manidipine for nephroprotection in diabetes (DEMAND) randomized clinical trial. P. Ruggenenti, G. Lauria, I. P. Iliev, A. Fassi, A. P. Ilieva, S. Rota, C. Chiurchiu, D. P. Barlovic, A. Sghirlanzoni, R. Lombardi, P. Penza, G. Cavaletti, M. L. Piatti, B. Frigeni, M. Filipponi, N. Rubis, G. Noris, N. Motterlini, B. Ene-Iordache, F. Gaspari, A. Perna, J. Zaletel, A. Bossi, A. R. Dodesini, R. Trevisan, G. Remuzzi and D. S. Investigators. Hypertension 2011: 776–83 21931073
Reduced progression of diabetic microvascular complications with islet cell transplantation compared with intensive medical therapy. D. M. Thompson, M. Meloche, Z. Ao, B. Paty, P. Keown, R. J. Shapiro, S. Ho, D. Worsley, M. Fung, G. Meneilly, I. Begg, M. Al Mehthel, J. Kondi, C. Harris, B. Fensom, S. E. Kozak, S. O. Tong, M. Trinh, G. L. Warnock. Transplantation 2011: 373–8
Long-term effects of a randomised trial of a 6-year lifestyle intervention in impaired glucose tolerance on diabetes-related microvascular complications: the China Da Qing Diabetes Prevention Outcome Study. Q. Gong, E. W. Gregg, J. Wang, Y. An, P. Zhang, W. Yang, H. Li, H. Li, Y. Jiang, Y. Shuai, B. Zhang, J. Zhang, R. B. Gerzoff, G. Roglic, Y. Hu, G. Li, P. H. Bennett. Diabetologia 2011: 300–7 21046360
Effect of intensive treatment of hyperglycaemia on microvascular outcomes in type 2 diabetes: an analysis of the ACCORD randomised trial. F. Ismail-Beigi, T. Craven, M. A. Banerji, J. Basile, J. Calles, R. M. Cohen, R. Cuddihy, W. C. Cushman, S. Genuth, R. H. Grimm, Jr., B. P. Hamilton, B. Hoogwerf, D. Karl, L. Katz, A. Krikorian, P. O’Connor, R. Pop-Busui, U. Schubart, D. Simmons, H. Taylor, A. Thomas, D. Weiss, I. Hramiak and A. t. group. Lancet 2010: 419–30
An exercise intervention to improve diabetic patients’ gait in a real-life environment. L. Allet, S. Armand, K. Aminian, Z. Pataky, A. Golay, R. A. de Bie, E. D. de Bruin. Gait Posture 2010: 185–90
Effect of prior intensive insulin treatment during the Diabetes Control and Complications Trial (DCCT) on peripheral neuropathy in type 1 diabetes during the Epidemiology of Diabetes Interventions and Complications (EDIC) Study. J. W. Albers, W. H. Herman, R. Pop-Busui, E. L. Feldman, C. L. Martin, P. A. Cleary, B. H. Waberski, J. M. Lachin, C. Diabetes, I. Complications Trial/Epidemiology of Diabetes and G. Complications Research. Diabetes Care 2010: 1090–6 20150297
Effect of intensive compared with standard glycemia treatment strategies on mortality by baseline subgroup characteristics: the Action to Control Cardiovascular Risk in Diabetes (ACCORD) trial. J. Calles-Escandon, L. C. Lovato, D. G. Simons-Morton, D. M. Kendall, R. Pop-Busui, R. M. Cohen, D. E. Bonds, V. A. Fonseca, F. Ismail-Beigi, M. A. Banerji, A. Failor, B. Hamilton. Diabetes Care 2010: 721–7 20103550
The gait and balance of patients with diabetes can be improved: a randomised controlled trial. L. Allet, S. Armand, R. A. de Bie, A. Golay, D. Monnin, K. Aminian, J. B. Staal, E. D. de Bruin. Diabetologia 2010: 458–66 19921145
Acupressure therapy inhibits the development of diabetic complications in Chinese patients with type 2 diabetes. K. K. Jin, L. Chen, J. Y. Pan, J. M. Li, Y. Wang, F. Y. Wang. J Altern Complement Med 2009: 1027–32 19757980
Examining correlates of treatment satisfaction for injectable insulin in type 2 diabetes: lessons learned from a clinical trial comparing biphasic and basal analogues. M. Brod, D. Cobden, M. Lammert, D. Bushnell, P. Raskin. Health Qual Life Outcomes 2007: 8 17286868
Exercise training can modify the natural history of diabetic peripheral neuropathy. S. Balducci, G. Iacobellis, L. Parisi, N. Di Biase, E. Calandriello, F. Leonetti, F. Fallucca. J Diabetes Complications 2006: 216–23 16798472
Glycemic control and the risk of multiple microvascular diabetic complications. K. G. Schellhase, T. D. Koepsell, N. S. Weiss. Fam Med 2005: 125–30 15690253
Diabetes, peripheral neuropathy, and old age disability. H. E. Resnick, K. B. Stansberry, T. B. Harris, M. Tirivedi, K. Smith, P. Morgan, A. I. Vinik. Muscle Nerve 2002: 43–50 11754184
The use of dynamic posturography to detect neurosensorial disorder in IDDM without clinical neuropathy. W. Di Nardo, G. Ghirlanda, S. Cercone, D. Pitocco, C. Soponara, A. Cosenza, G. Paludetti, M. A. Di Leo, I. Galli. J Diabetes Complications 1999: 79–85 10432171
Diabetic neuropathy in elderly Type 2 diabetic patients: effects of insulin treatment. J. Tovi, E. Svanborg, B. Y. Nilsson, P. Engfeldt. Acta Neurol Scand 1998: 346–53 9858106
Is there a critical level of plantar foot pressure to identify patients at risk for neuropathic foot ulceration?. D. G. Armstrong, E. J. Peters, K. A. Athanasiou, L. A. Lavery. J Foot Ankle Surg 1998: 303–7 9710782
Intensive insulin therapy prevents the progression of diabetic microvascular complications in Japanese patients with non-insulin-dependent diabetes mellitus: a randomized prospective 6-year study. Y. Ohkubo, H. Kishikawa, E. Araki, T. Miyata, S. Isami, S. Motoyoshi, Y. Kojima, N. Furuyoshi, M. Shichiri. Diabetes Res Clin Pract 1995: 103–17 7587918
The effect of intensive diabetes therapy on the development and progression of neuropathy. The Diabetes Control and Complications Trial Research Group. . Ann Intern Med 1995: 561–8
Tolrestat in the primary prevention of diabetic neuropathy. D. Giugliano, R. Acampora, R. Marfella, G. Di Maro, N. De Rosa, L. Misso, A. Ceriello, A. Quatraro, F. D’Onofrio. Diabetes Care 1995: 536–41 7497865
Are there any glycemic thresholds for the serious microvascular diabetic complications?. P. Reichard. J Diabetes Complications 1995: 25–30 7734740
The effect of intensive treatment of diabetes on the development and progression of long-term complications in insulin-dependent diabetes mellitus. The Diabetes Control and Complications Trial Research Group. . N Engl J Med 1993: 977–86 8366922
Reduction of lower extremity clinical abnormalities in patients with non-insulin-dependent diabetes mellitus. A randomized, controlled trial. D. K. Litzelman, C. W. Slemenda, C. D. Langefeld, L. M. Hays, M. A. Welch, D. E. Bild, E. S. Ford, F. Vinicor. Ann Intern Med 1993: 36–41 8498761
Diabetic neuropathy: effects of intensified glycaemic control with multiple insulin injections. N. Hotta, R. Kawamori, T. Sano, H. Kakuta, T. Kamada, N. Sakamoto. Diabet Med 1993: 91S–94S 8334854
Problems with gait and posture in neuropathic patients with insulin-dependent diabetes mellitus. P. R. Cavanagh, J. A. Derr, J. S. Ulbrecht, R. E. Maser, T. J. Orchard. Diabet Med 1992: 469–74 1611836
Intensified conventional insulin treatment retards the microvascular complications of insulin-dependent diabetes mellitus (IDDM): the Stockholm Diabetes Intervention Study (SDIS) after 5 years. P. Reichard, B. Berglund, A. Britz, I. Cars, B. Y. Nilsson, U. Rosenqvist. J Intern Med 1991: 101–8 1865159
The association of physical activity and diabetic complications in individuals with insulin-dependent diabetes mellitus: the Epidemiology of Diabetes Complications Study--VII. A. M. Kriska, R. E. LaPorte, S. L. Patrick, L. H. Kuller, T. J. Orchard. J Clin Epidemiol 1991: 1207–14 1941015
Metabolic control and complications over 3 years in patients with insulin dependent diabetes (IDDM): the Stockholm Diabetes Intervention Study (SDIS). P. Reichard, A. Britz, P. Carlsson, I. Cars, L. Lindblad, B. Y. Nilsson, U. Rosenqvist. J Intern Med 1990: 511–7 2254723
Metformin, methylmalonic acid and the risk of neuropathy: A randomised placebo-controlled trial. M. Out, A. Kooy, P. Lehert, C. G. Schalkwijk, C. D. A. Stehouwer. Diabetologia 2015: S110–S111
Plasma glucose monitoring and the subsequent HbA1c control in patients with type 2 diabetes on a basal supported oral therapy regimen in real life: subanalysis of the ALOHA study: a 24-week, prospective, open-label, multicenter, observational study. M. Odawara, T. Kadowaki, Y. Naito. Diabetology International 2015: 66–76
Long-term effects of lifestyle intervention or metformin on diabetes development and microvascular complications over 15-year follow-up: The Diabetes Prevention Program Outcomes Study. D. M. Nathan, E. Barrett-Connor, J. P. Crandall, S. L. Edelstein, R. B. Goldberg, E. S. Horton, W. C. Knowler, K. J. Mather, T. J. Orchard, X. Pi-Sunyer, D. Schade, M. Temprosa. The Lancet Diabetes and Endocrinology 2015: 866–875 26377054
Incidence and impact of hypoglycemia in diabetic patients with intensified glycaemic control in clinical practice-results of DiaRegis. A. K. Gitt, P. Bramlage, S. Schneider, C. Binz, M. Krekler, D. Tschoepe. European Heart Journal 2014: 1020–1021
Regular exercise improves metabolic control and reduces chronic complications in patients with type 2 diabetes. J. Tang, X. Li, Y. Yang, L. Yuan, J. Han, C. Ju, L. Shen, Q. Lou, F. Zhao, Z. Sun, X. Guo. Diabetologia 2014: S434
Macro- and microvascular outcomes in patients with type 2 diabetes treated with rapid-acting insulin analogues or human regular insulin: A retrospective database analysis. W. Rathmann, N. C. Schloot, K. Kostev, M. Reaney, A. J. Zagar, A. Haupt. Experimental and Clinical Endocrinology and Diabetes 2014: 92–99 24558019
Efficacy and safety of sitagliptin added to ongoing metformin and rosiglitazone combination therapy in a randomized placebo-controlled 54-week trial in patients with type 2 diabetes. A. S. Dobs, B. J. Goldstein, P. Aschner, E. S. Horton, G. E. Umpierrez, L. Duran, J. S. Hill, Y. Chen, G. T. Golm, R. B. Langdon, D. E. Williams-Herman, K. D. Kaufman, J. M. Amatruda, J. C. A. Ferreira. Journal of Diabetes 2013: 68–79
Assessment of glycemic control in korean patients with type 2 diabetes mellitus treated with metformin+sulfonylurea: Results of alit study. H. Y. Kim, S. G. Kim, J. R. Hahm, D. K. Kim, S. R. Cho, D. S. Choi. Endocrine Reviews 2013:
Efficacy of Pregabalin for Peripheral Neuropathic Pain: Results of an 8-Week, Flexible-Dose, Double-Blind, Placebo-Controlled Study Conducted in China. Y. Guan, X. Ding, Y. Cheng, D. Fan, L. Tan, Y. Wang, Z. Zhao, Z. Hong, D. Zhou, X. Pan, S. Chen, A. Martin, H. Tang, L. Cui. Clinical Therapeutics 2011: 159–166 21444113
Impact of exercise intensity and duration on insulin sensitivity in women with T2D. B. Segerström AB, F. Glans, K. F. Eriksson, A. M. Holmbäck, L. Groop, O. Thorsson, P. Wollmer. European Journal of Internal Medicine 2010: 404–408 20816594
Dose-ranging efficacy of sitagliptin, a dipeptidyl peptidase-4 inhibitor, in Japanese patients with type 2 diabetes mellitus. Y. Iwamoto, T. Taniguchi, K. Nonaka, T. Okamoto, K. Okuyama, J. C. A. Ferreira, J. Amatruda. Endocrine Journal 2010: 383–394 20332588
The role of physical examination in the diagnosis of chronic sensorimotor distal symmetric polyneuropathy in patients with diabetes mellitus. M. Jasik, A. Niebisz, A. Cacko, M. Cenkier, M. Cacko, W. Karnafel. Diabetologia Doswiadczalna i Kliniczna 2009: 17–23
Efficacy and safety of sitagliptin added to ongoing metformin therapy in patients with type 2 diabetes. I. Raz, Y. Chen, M. Wu, S. Hussain, K. D. Kaufman, J. M. Amatruda, R. B. Langdon, P. P. Stein, M. Alba. Current Medical Research and Opinion 2008: 537–550 18194595
Relationships between diabetic peripheral neuropathy and affective factors. L. Qin, J. Yin, H. L. Xing. Chinese Journal of Clinical Rehabilitation 2004: 5154–5155
Effect of intensive therapy on the microvascular complications of type 1 diabetes mellitus. S. Genuth, J. Lipps, G. Lorenzi, D. M. Nathan, M. D. Davis, J. M. Lachin, P. A. Cleary. Journal of the American Medical Association 2002: 2563–2569 12020338
Management of midfoot diabetic neuroarthropathy. M. S. Myerson, M. R. Henderson, T. Saxby, K. W. Short. Foot and Ankle International 1994: 233–241 7951961
A preliminary report on diabetes control and complication trial (DCCT). A. Secchi, M. R. Pastore. Italian Journal of Ophthalmology 1993: 163–166
The effect of intensive treatment of diabetes on the development and progression of long-term complications in insulin-dependent diabetes mellitus. H. Shamoon, H. Duffy, N. Fleischer, S. Engel, P. Saenger, M. Strelzyn, M. Litwak, J. Wylie-Rosett, A. Farkash, D. Geiger, H. Engel, J. Fleischman, D. Pompi, N. Ginsberg, M. Glover, M. Brisman, E. Walker, A. Thomashunis, J. Gonzalez. New England Journal of Medicine 1993: 977–986 8366922
Effect of near normoglycaemia for two years on progression of early diabetic retinopathy, nephropathy, and neuropathy: the Oslo study. K. Dahl Jørgensen, O. Brinchmann Hansen, K. F. Hanssen, T. Ganes, P. Kierulf, E. Smeland, L. Sandvik, O. Aagenaes. Br Med J (Clin Res Ed) 1986: 1195–9
The gait and balance of patients with diabetes can be improved: a randomised controlled trial. L. Allet, S. Armand, R. A. Bie, A. Golay, D. Monnin, K. Aminian, J. B. Staal, E. D. Bruin. Diabetologia 2010: 458–66 19921145
Walking performance in people with diabetic neuropathy: benefits and threats. R. V. Kanade, R. W. Deursen, K. Harding, P. Price. Diabetologia 2006: 1747–54 16758177
Two-year experience with continuous subcutaneous insulin infusion in relation to retinopathy and neuropathy. T. Lauritzen, K. Frost Larsen, H. W. Larsen, T. Deckert. Diabetes 1985: 74–9
Impact of glycemic control strategies on the progression of diabetic peripheral neuropathy in the Bypass Angioplasty Revascularization Investigation 2 Diabetes (BARI 2D) Cohort. R. Pop Busui, J. Lu, M. M. Brooks, S. Albert, A. D. Althouse, J. Escobedo, J. Green, P. Palumbo, B. A. Perkins, F. Whitehouse, T. L. Jones. Diabetes Care 2013: 3208–15 23757426
Effect of intensive treatment of hyperglycaemia on microvascular outcomes in type 2 diabetes: an analysis of the ACCORD randomised trial. F. Ismail Beigi, T. Craven, M. A. Banerji, J. Basile, J. Calles, R. M. Cohen, R. Cuddihy, W. C. Cushman, S. Genuth, R. H. Grimm, B. P. Hamilton, B. Hoogwerf, D. Karl, L. Katz, A. Krikorian, P. O’Connor, R. Pop Busui, U. Schubart, D. Simmons, H. Taylor, A. Thomas, D. Weiss, I. Hramiak. Lancet 2010: 419–30
Exercise training can modify the natural history of diabetic peripheral neuropathy. S. Balducci, G. Iacobellis, L. Parisi, N. Biase, E. Calandriello, F. Leonetti, F. Fallucca. J Diabetes Complications 2006: 216–23 16798472
Glucose control and vascular complications in veterans with type 2 diabetes. W. Duckworth, C. Abraira, T. Moritz, D. Reda, N. Emanuele, P. D. Reaven, F. J. Zieve, J. Marks, S. N. Davis, R. Hayward, S. R. Warren, S. Goldman, M. McCarren, M. E. Vitek, W. G. Henderson, G. D. Huang. New England Journal of Medicine 2009: 129–39 19092145
Metabolic control and complications of 3 years in patients with insulin dependent diabetes (IDDM): The Stockholm Diabetes Intervention Study (SDIS). P. Reichard, A. Britz, P. Carlsson, I. Cars, L. Lindblad, B. Y. Nilsson. J Intern Med 1990: 511–7 2254723
Randomised controlled clinical trial for autologous fibroblast-hyaluronic acid complex in treating diabetic foot ulcers. H. J. You, S. K. Han, J. W. Rhie. J Wound Care 2014: 521–2, 524, 526–30
Self-care and misplaced confidence: A randomised controlled trial of provision of VibraTip for patients with diabetes at high risk of complications. A. Levy, A. Cole, R. Greenwood. Practical Diabetes 2014: 199–201
Microsurgical Reconstruction of Plantar Ulcers of the Insensate Foot. D. Kadam. J Reconstr Microsurg 2016:
A prospective, randomized, multicenter trial comparing the efficacy and safety of the concurrent use of long-acting insulin with mitiglinide or voglibose in patients with type 2 diabetes. J. W. Son, I. K. Lee, J. T. Woo, S. H. Baik, H. C. Jang, K. W. Lee, B. S. Cha, Y. A. Sung, T. S. Park, S. J. Yoo, K. H. Yoon. Endocr J 2015: 1049–1057 26411328
Incidence of microvascular outcomes in type 2 diabetes patients treated with vildagliptin vs sulphonylurea: A retrospective study using German electronic medical records. W. M. Kolaczynski, M. Hankins, S. H. Ong, H. Richter, A. Clemens, M. Toussi. Diabetologia 2015: S394
Effects of Buerger Exercise Combined Health-Promoting Program on Peripheral Neurovasculopathy Among Community Residents at High Risk for Diabetic Foot Ulceration. C. F. Chang, C. C. Chang, S. L. Hwang, M. Y. Chen. Worldviews Evid Based Nurs 2015: 145–153 25963925
Long-term effects of lifestyle intervention or metformin on diabetes development and microvascular complications over 15-year follow-up: The Diabetes Prevention Program Outcomes Study. D. M. Nathan, E. Barrett-Connor, J. P. Crandall, S. L. Edelstein, R. B. Goldberg, E. S. Horton, W. C. Knowler, K. J. Mather, T. J. Orchard, X. Pi-Sunyer, D. Schade, M. Temprosa. The Lancet Diabetes and Endocrinology 2015: 866–875 26377054
Long-term effects of lifestyle intervention or metformin on diabetes development and microvascular complications over 15-year follow-up: the Diabetes Prevention Program Outcomes Study.. Lancet Diabetes Endocrinol 2015: 866–75 26377054

### No outcome of interest

Long-term effects of lifestyle intervention or metformin on diabetes development and microvascular complications over 15-year follow-up: the Diabetes Prevention Program Outcomes Study. G. Diabetes Prevention Program Research. Lancet Diabetes Endocrinol 2015:
Glycemic Control and Mortality in Diabetic Patients Undergoing Dialysis Focusing on the Effects of Age and Dialysis Type: A Prospective Cohort Study in Korea. J. I. Park, E. Bae, Y. L. Kim, S. W. Kang, C. W. Yang, N. H. Kim, J. P. Lee, D. K. Kim, K. W. Joo, Y. S. Kim, H. Lee. PLoS One 2015: e0136085 26285034
Assessment of the rocker sole shoes on postural stability in diabetic patients with distal sensory neuropathy. M. Lumeau, M. Lempereur, O. Remy-Neris. Comput Methods Biomech Biomed Engin 2015: 1986–7 26269202
Pedobarometric evaluation of specific shoe wearing in patients with diabetic peripheral neuropathy. K. Choplin, J. M. Audebrand, B. Beaune. Comput Methods Biomech Biomed Engin 2015: 1902–3 26244483
Metformin: Potential analgesic?. B. Smith, D. Ang. Pain Med 2015:
Relationship between beta-cell function, metabolic control, and microvascular complications in type 2 diabetes mellitus. L. Zhao, J. Ma, S. Wang, Y. Xie. Diabetes Technol Ther 2015: 29–34
Completion report: Effect of Comprehensive Yogic Breathing program on type 2 diabetes: A randomized control trial. V. P. Jyotsna, A. Dhawan, V. Sreenivas, K. K. Deepak, R. Singla. Indian J Endocrinol Metab 2014: 582–4 25143922
Continuous subcutaneous insulin infusion preserves axonal function in type 1 diabetes mellitus. N. Kwai, R. Arnold, A. M. Poynten, C. S. Lin, M. C. Kiernan, A. V. Krishnan. Diabetes Metab Res Rev 2015: 175–82 25066412
Effect of aerobic exercise on peripheral nerve functions of population with diabetic peripheral neuropathy in type 2 diabetes: a single blind, parallel group randomized controlled trial. S. Dixit, A. G. Maiya, B. A. Shastry. J Diabetes Complications 2014: 332–9 24507164
Investigating the role of backward walking therapy in alleviating plantar pressure of patients with diabetic peripheral neuropathy. X. Zhang, Y. Zhang, X. Gao, J. Wu, X. Jiao, J. Zhao, X. Lv. Arch Phys Med Rehabil 2014: 832–9 24445089
Neuropathy and related findings in the diabetes control and complications trial/epidemiology of diabetes interventions and complications study. C. L. Martin, J. W. Albers, R. Pop-Busui and D. E. R. Group. Diabetes Care 2014: 31–8 24356595
Lower leg muscle strengthening does not redistribute plantar load in diabetic polyneuropathy: a randomised controlled trial. T. Melai, N. C. Schaper, T. H. Ijzerman, T. L. de Lange, P. J. Willems, V. Lima Passos, A. G. Lieverse, K. Meijer, H. H. Savelberg. J Foot Ankle Res 2013: 41 24138784
Effects of physical activity on the development and progression of microvascular complications in type 1 diabetes: retrospective analysis of the DCCT study. C. B. Makura, K. Nirantharakumar, A. J. Girling, P. Saravanan, P. Narendran. BMC Endocr Disord 2013: 37 24083407
Impact of glycemic control strategies on the progression of diabetic peripheral neuropathy in the Bypass Angioplasty Revascularization Investigation 2 Diabetes (BARI 2D) Cohort. R. Pop-Busui, J. Lu, M. M. Brooks, S. Albert, A. D. Althouse, J. Escobedo, J. Green, P. Palumbo, B. A. Perkins, F. Whitehouse, T. L. Jones and B. D. S. Group. Diabetes Care 2013: 3208–15 23757426
Effects of the endpoint adjudication process on the results of a randomised controlled trial: the ADVANCE trial. J. Hata, H. Arima, S. Zoungas, G. Fulcher, C. Pollock, M. Adams, J. Watson, R. Joshi, A. P. Kengne, T. Ninomiya, C. Anderson, M. Woodward, A. Patel, G. Mancia, N. Poulter, S. MacMahon, J. Chalmers, B. Neal and A. C. Group. PLoS One 2013: e55807 23390553
Mortality and other important diabetes-related outcomes with insulin vs other antihyperglycemic therapies in type 2 diabetes. C. J. Currie, C. D. Poole, M. Evans, J. R. Peters, C. L. Morgan. J Clin Endocrinol Metab 2013: 668–77 23372169
Observational study of the association of first insulin type in uncontrolled type 2 diabetes with macrovascular and microvascular disease. G. C. Hall, A. D. McMahon, D. Carroll, P. D. Home. PLoS One 2012: e49908 23166795
Lower incidence of recorded cardiovascular outcomes in patients with type 2 diabetes using insulin aspart vs. those on human regular insulin: observational evidence from general practices. W. Rathmann, K. Kostev. Diabetes Obes Metab 2013: 358–63 23137345
Botulinum toxin effects on gasatrocnemius strength and plantar pressure in diabetics with peripheral neuropathy and forefoot ulceration. M. K. Hastings, M. J. Mueller, D. R. Sinacore, M. J. Strube, B. E. Crowner, J. E. Johnson, B. R. Racette. Foot Ankle Int 2012: 363–70 22735277
Pressure-reduction and preservation in custom-made footwear of patients with diabetes and a history of plantar ulceration. R. Waaijman, M. L. Arts, R. Haspels, T. E. Busch-Westbroek, F. Nollet, S. A. Bus. Diabet Med 2012: 1542–9 22540919
Effects of a combined strengthening, stretching and functional training program versus usual-care on gait biomechanics and foot function for diabetic neuropathy: a randomized controlled trial. C. D. Sartor, R. Watari, A. C. Passaro, A. P. Picon, R. H. Hasue, I. C. Sacco. BMC Musculoskelet Disord 2012: 36 22429765
Acupressure therapy inhibits the development of diabetic complications in Chinese patients with type 2 diabetes. K. K. Jin, L. Chen, J. Y. Pan, J. M. Li, Y. Wang, F. Y. Wang. J Altern Complement Med 2009: 1027–32 19757980
Long-standing, insulin-treated type 2 diabetes patients with complications respond well to short-term resistance and interval exercise training. S. F. Praet, R. A. Jonkers, G. Schep, C. D. Stehouwer, H. Kuipers, H. A. Keizer, L. J. van Loon. Eur J Endocrinol 2008: 163–72 18230822
Nonwindowed nonremovable fiberglass off-loading cast versus removable pneumatic cast (AircastXP Diabetic Walker) in the treatment of neuropathic noninfected plantar ulcers: a randomized prospective trial. C. Caravaggi, A. Sganzaroli, M. Fabbi, P. Cavaiani, I. Pogliaghi, R. Ferraresi, F. Capello, A. Morabito. Diabetes Care 2007: 2577–8 17563333
Established diabetic neuropathy seems irreversible despite improvements in metabolic and vascular risk markers--a retrospective case-control study in a hospital patient cohort. D. V. Coppini, M. C. Spruce, P. Thomas, M. G. Masding. Diabet Med 2006: 1016–20 16922709
Therapeutic efficacy of ozone in patients with diabetic foot. G. Martinez-Sanchez, S. M. Al-Dalain, S. Menendez, L. Re, A. Giuliani, E. Candelario-Jalil, H. Alvarez, J. I. Fernandez-Montequin, O. S. Leon. Eur J Pharmacol 2005: 151–61
Interventions improve gait regularity in patients with peripheral neuropathy while walking on an irregular surface under low light. J. K. Richardson, S. B. Thies, T. K. DeMott, J. A. Ashton-Miller. J Am Geriatr Soc 2004: 510–5 15066064
Effect of Yoga asanas on nerve conduction in type 2 diabetes. V. Malhotra, S. Singh, O. P. Tandon, S. V. Madhu, A. Prasad, S. B. Sharma. Indian J Physiol Pharmacol 2002: 298–306 12613392
Diabetic neuropathy in elderly Type 2 diabetic patients: effects of insulin treatment. J. Tovi, E. Svanborg, B. Y. Nilsson, P. Engfeldt. Acta Neurol Scand 1998: 346–53 9858106
Effect of intensive diabetes management on macrovascular events and risk factors in the Diabetes Control and Complications Trial.. Am J Cardiol 1995: 894–903 7732997
Prevention of coronary heart disease and stroke complications in type 2 diabetes mellitus: An observational, prospective study. R. M. Ştefan, C. Niţă, A. Crăciun, A. Rusu, N. Hâncu. Romanian Journal of Diabetes, Nutrition and Metabolic Diseases 2015: 175–185
Can vibratory insoles improve gait in patients with diabetic peripheral neuropathy?. G. M. Ramzy, G. M. Ahmed, D. M. Labib, A. F. Genedy, S. G. Abdelwahab. Egyptian Journal of Neurology, Psychiatry and Neurosurgery 2015: 147–151
Continued smoking exacerbates but cessation ameliorates progression of early type 2 diabetic complications. V. Voulgaris, C. Voulgari, P. Dilaveris, C. Tsioufis, N. Katsilambros, C. Stefanadis, N. Tentolouris. Diabetologia 2011: S377
Gait, balance and plantar temperature fluctuation in charcot and diabetes patients with and without active foot ulcer. B. Najafi, G. S. Grewal, R. A. Menzies, T. K. Talal, M. A. Zirie, D. G. Armstrong. Diabetes 2011: A18
Dose-ranging efficacy of sitagliptin, a dipeptidyl peptidase-4 inhibitor, in Japanese patients with type 2 diabetes mellitus. Y. Iwamoto, T. Taniguchi, K. Nonaka, T. Okamoto, K. Okuyama, J. C. A. Ferreira, J. Amatruda. Endocrine Journal 2010: 383–394 20332588
A 6-month, randomized, double-masked, placebo-controlled study evaluating the effects of the protein kinase C-β inhibitor ruboxistaurin on skin microvascular blood flow and other measures of diabetic peripheral neuropathy. C. M. Casellini, P. M. Barlow, A. L. Rice, M. Casey, K. Simmons, G. Pittenger, I. E. J. Bastyr, A. M. Wolka, A. I. Vinik. Diabetes Care 2007: 896–902 17392551
Effect of intensive therapy on the microvascular complications of type 1 diabetes mellitus. S. Genuth, J. Lipps, G. Lorenzi, D. M. Nathan, M. D. Davis, J. M. Lachin, P. A. Cleary. Journal of the American Medical Association 2002: 2563–2569 12020338
A preliminary report on diabetes control and complication trial (DCCT). A. Secchi, M. R. Pastore. Italian Journal of Ophthalmology 1993: 163–166
Effect of near normoglycaemia for two years on progression of early diabetic retinopathy, nephropathy, and neuropathy: the Oslo study. K. Dahl J⊘rgensen, O. Brinchmann Hansen, K. F. Hanssen, T. Ganes, P. Kierulf, E. Smeland, L. Sandvik, O. Aagenaes. Br Med J (Clin Res Ed) 1986: 1195–9
The gait and balance of patients with diabetes can be improved: a randomised controlled trial. L. Allet, S. Armand, R. A. Bie, A. Golay, D. Monnin, K. Aminian, J. B. Staal, E. D. Bruin. Diabetologia 2010: 458–66 19921145
Effect of intensive treatment of hyperglycaemia on microvascular outcomes in type 2 diabetes: an analysis of the ACCORD randomised trial. F. Ismail Beigi, T. Craven, M. A. Banerji, J. Basile, J. Calles, R. M. Cohen, R. Cuddihy, W. C. Cushman, S. Genuth, R. H. Grimm, B. P. Hamilton, B. Hoogwerf, D. Karl, L. Katz, A. Krikorian, P. O’Connor, R. Pop Busui, U. Schubart, D. Simmons, H. Taylor, A. Thomas, D. Weiss, I. Hramiak. Lancet 2010: 419–30
Motor learning of a gait pattern to reduce forefoot plantar pressures in individuals with diabetic peripheral neuropathy. R. M. York, K. L. Perell Gerson, M. Barr, J. Durham, J. M. Roper. PM R 2009: 434–41 19627930
Frequency-modulated electromagnetic neural stimulation enhances cutaneous microvascular flow in patients with diabetic neuropathy. M. Conti, E. Peretti, G. Cazzetta, G. Galimberti, C. Vermigli, R. Pola, L. Scionti, E. Bosi. J Diabetes Complications 2009: 46–8 18403219
The effect of 8 years of strict glycaemic control on peripheral nerve function in IDDM patients: the Oslo Study. K. F. Amthor, K. Dahl J⊘rgensen, T. J. Berg, M. S. Heier, L. Sandvik, O. Aagenaes, K. F. Hanssen. Diabetologia 1994: 579–84 7926342
Short-term effects of the whole-body vibration on the balance and muscle strength of type 2 diabetic patients with peripheral neuropathy: A quasi-randomized-controlled trial study. A. Kordi Yoosefinejad, A. Shadmehr, G. Olyaei, S. Talebian, H. Bagheri, M. R. Mohajeri Tehrani. J Diabetes Metab Disord 2015:
Aldosterone blockade attenuates urinary monocyte chemoattractant protein-1 and oxidative stress in patients with type 2 diabetes complicated by diabetic nephropathy. K. Takebayashi, S. Matsumoto, Y. Aso, T. Inukai. Journal of Clinical Endocrinology and Metabolism 2006: 2214–7 16569732
Effect of ruboxistaurin on albuminuria and estimated GFR in people with diabetic peripheral neuropathy: Results from a randomized trial. K. R. Tuttle, J. B. McGill, E. J. Bastyr, K. K. Poi, N. Shahri, P. W. Anderson. American Journal of Kidney Diseases 2015: 634–6 25618186
Effect of surgical decompression of nerves in the lower extremity in patients with painful diabetic polyneuropathy on stability: a randomized controlled trial. J. F. Macare van Maurik, B. Ter Horst, M. van Hal, M. Kon, E. J. Peters. Clin Rehabil 2015: 994–1001 25381348
Prospective evaluation of the effect of short-term oral vitamin D supplementation on peripheral neuropathy in type 2 diabetes mellitus. D. Shehab, K. Al-Jarallah, N. Abdella, O. A. Mojiminiyi, H. Al Mohamedy. Medical Principles and Practice 2015: 250–6 25720672
Can vibratory insoles improve gait in patients with diabetic peripheral neuropathy?. G. M. Ramzy, G. M. Ahmed, D. M. Labib, A. F. Genedy, S. G. Abdelwahab. Egyptian Journal of Neurology, Psychiatry and Neurosurgery 2015: 147–51
A prospective, randomized, multicenter trial comparing the efficacy and safety of the concurrent use of long-acting insulin with mitiglinide or voglibose in patients with type 2 diabetes. J. W. Son, I. K. Lee, J. T. Woo, S. H. Baik, H. C. Jang, K. W. Lee, B. S. Cha, Y. A. Sung, T. S. Park, S. J. Yoo, K. H. Yoon. Endocr J 2015: 1049–1057 26411328
Incidence of microvascular outcomes in type 2 diabetes patients treated with vildagliptin vs sulphonylurea: A retrospective study using German electronic medical records. W. M. Kolaczynski, M. Hankins, S. H. Ong, H. Richter, A. Clemens, M. Toussi. Diabetologia 2015: S394
Effects of exenatide on measures of diabetic neuropathy in subjects with type 2 diabetes: Results from an 18-month proof-of-concept open-label randomized study. M. Jaiswal, C. L. Martin, M. B. Brown, B. Callaghan, J. W. Albers, E. L. Feldman, R. Pop-Busui. J Diabetes Complications 2015: 1287–1294 26264399
Effects of thai foot massage on balance performance in diabetic patients with peripheral neuropathy: a randomized parallel-controlled trial. U. Chatchawan, W. Eungpinichpong, P. Plandee, J. Yamauchi. Med Sci Monit Basic Res 2015: 68–75 25892354
Long-term effects of lifestyle intervention or metformin on diabetes development and microvascular complications over 15-year follow-up: The Diabetes Prevention Program Outcomes Study. D. M. Nathan, E. Barrett-Connor, J. P. Crandall, S. L. Edelstein, R. B. Goldberg, E. S. Horton, W. C. Knowler, K. J. Mather, T. J. Orchard, X. Pi-Sunyer, D. Schade, M. Temprosa. The Lancet Diabetes and Endocrinology 2015: 866–875 26377054
Analysis of Postural Control During Quiet Standing in a Population with Diabetic Peripheral Neuropathy Undergoing Moderate Intensity Aerobic Exercise Training: A Single Blind, Randomized Controlled Trial. S. Dixit, A. Maiya, B. A. Shastry, V. Guddattu. Am J Phys Med Rehabil 2016:
Implementation of foot thermometry plus mHealth to prevent diabetic foot ulcers: study protocol for a randomized controlled trial. M. Lazo-Porras, A. Bernabe-Ortiz, K. A. Sacksteder, R. H. Gilman, G. Malaga, D. G. Armstrong, J. J. Miranda. Trials 2016: 206 27094007
A randomized controlled trial comparing treatment with oral agents and basal insulin in elderly patients with type 2 diabetes in long-term care facilities. F. J. Pasquel, W. Powell, L. Peng, T. M. Johnson, S. Sadeghi-Yarandi, C. Newton, D. Smiley, M. T. Toyoshima, P. Aram, G. E. Umpierrez. BMJ Open Diabetes Research and Care 2015:

### Does not evaluate an intervention of interest

Influence of remission and its duration on development of early microvascular complications in young adults with type 1 diabetes. P. Niedzwiecki, S. Pilacinski, A. Uruska, A. Adamska, D. Naskret, D. Zozulinska-Ziolkiewicz. J Diabetes Complications 2015:
Glycemic Control and Mortality in Diabetic Patients Undergoing Dialysis Focusing on the Effects of Age and Dialysis Type: A Prospective Cohort Study in Korea. J. I. Park, E. Bae, Y. L. Kim, S. W. Kang, C. W. Yang, N. H. Kim, J. P. Lee, D. K. Kim, K. W. Joo, Y. S. Kim, H. Lee. PLoS One 2015: e0136085 26285034
Topically Applied Vancomycin Powder Reduces the Rate of Surgical Site Infection in Diabetic Patients Undergoing Foot and Ankle Surgery. D. K. Wukich, J. W. Dikis, S. J. Monaco, K. Strannigan, N. C. Suder, B. L. Rosario. Foot Ankle Int 2015: 1017–24 25967254
Relationship between beta-cell function, metabolic control, and microvascular complications in type 2 diabetes mellitus. L. Zhao, J. Ma, S. Wang, Y. Xie. Diabetes Technol Ther 2015: 29–34
Effect of rosuvastatin on diabetic polyneuropathy: a randomized, double-blind, placebo-controlled Phase IIa study. J. Hernandez-Ojeda, L. M. Roman-Pintos, A. D. Rodriguez-Carrizalez, R. Troyo-Sanroman, E. G. Cardona-Munoz, P. Alatorre-Carranza Mdel, A. G. Miranda-Diaz. Diabetes Metab Syndr Obes 2014: 401–7 25214797
Assessment of antioxidant supplementation on the neuropathic pain score and quality of life in diabetic neuropathy patients - a randomized controlled study. M. G. Rajanandh, S. Kosey, G. Prathiksha. Pharmacol Rep 2014: 44–8
Obese patients with diabetes mellitus type 2 undergoing gastric bypass in Roux-en-Y: analysis of results and its influence in complications. J. L. Zeve, C. A. Tomaz, P. A. Nassif, J. H. Lima, L. R. Sansana, C. H. Zeve. Arq Bras Cir Dig 2013: 47–52 24463899
Offloading effect of therapeutic footwear in patients with diabetic neuropathy at high risk for plantar foot ulceration. M. L. Arts, R. Waaijman, M. de Haart, R. Keukenkamp, F. Nollet, S. A. Bus. Diabet Med 2012: 1534–41 22913552
Lower extremity muscle strength is reduced in people with type 2 diabetes, with and without polyneuropathy, and is associated with impaired mobility and reduced quality of life. I. J. TH, N. C. Schaper, T. Melai, K. Meijer, P. J. Willems, H. H. Savelberg. Diabetes Res Clin Pract 2012: 345–51 22104262
Potential risk factors for diabetic neuropathy: a case control study. F. Booya, F. Bandarian, B. Larijani, M. Pajouhi, M. Nooraei, J. Lotfi. BMC Neurol 2005: 24 16336693
Multicenter study of the incidence of and predictive risk factors for diabetic neuropathic foot ulceration. C. A. Abbott, L. Vileikyte, S. Williamson, A. L. Carrington, A. J. Boulton. Diabetes Care 1998: 1071–5 9653597
Evaluation of the efficacy of thiamine and pyridoxine in the treatment of symptomatic diabetic peripheral neuropathy. Z. G. Abbas, A. B. Swai. East Afr Med J 1997: 803–8 9557427
Tolrestat in the primary prevention of diabetic neuropathy. D. Giugliano, R. Acampora, R. Marfella, G. Di Maro, N. De Rosa, L. Misso, A. Ceriello, A. Quatraro, F. D’Onofrio. Diabetes Care 1995: 536–41 7497865
Differential effects of near-normoglycaemia for 4 years on somatic nerve dysfunction and heart rate variation in type 1 diabetic patients. D. Ziegler, K. Dannehl, K. Wiefels, F. A. Gries. Diabet Med 1992: 622–9 1511568
Early treatment of diabetic neuropathy. X. L. Zhong, B. D. Zheng, G. X. Hu, X. X. Zhu, Z. M. Hu. Chin Med J (Engl) 1981: 503–8 6791891
Effect of roux-en-y gastric bypass surgery on microvascular complications of type 2 diabetes mellitus. L. L. Chuah, A. D. Miras, D. Papamargaritis, A. Vusiri Kala, S. N. Jackson, N. Oliver, T. Olbers, C. W. Le Roux. Diabetes 2014: A525
Continued smoking exacerbates but cessation ameliorates progression of early type 2 diabetic complications. V. Voulgaris, C. Voulgari, P. Dilaveris, C. Tsioufis, N. Katsilambros, C. Stefanadis, N. Tentolouris. Diabetologia 2011: S377
A prospective, open-label, multicentre study of pregabalin in the treatment of neuropathic pain in Latin America. M. Xochilcal-Morales, E. M. Castro, J. Guajardo-Rosas, T. N. Obregón, J. C. Acevedo, J. M. G. Chucan, R. Plancarte-Sanchez, G. Davila, D. Wajsbrot, M. Guerrero, R. Vinueza. International Journal of Clinical Practice 2010: 1301–1309 20487048
A 6-month, randomized, double-masked, placebo-controlled study evaluating the effects of the protein kinase C-β inhibitor ruboxistaurin on skin microvascular blood flow and other measures of diabetic peripheral neuropathy. C. M. Casellini, P. M. Barlow, A. L. Rice, M. Casey, K. Simmons, G. Pittenger, I. E. J. Bastyr, A. M. Wolka, A. I. Vinik. Diabetes Care 2007: 896–902 17392551
C-peptide replacement therapy and sensory nerve function in type 1 diabetic neuropathy. K. Ekberg, T. Brismar, B. L. Johansson, P. Lindström, L. Juntti-Berggren, A. Norrby, C. Berne, H. J. Arnqvist, J. Bolinder, J. Wahren. Diabetes Care 2007: 71–76 17192336
The Sorbinil Retinopathy Trial: Neuropathy results. S. Carlison, W. Coles, D. Costigan, L. Curtis, E. Hedaya, D. Klements, T. Meredith, P. Sternberg Jr, R. Swords, J. Belt, D. Cornblath, A. Georgopoulis, J. Griffin, R. Murphy, D. Rytel, C. Saudek, J. Carl, P. Ciatto, D. Seigel. Neurology 1993: 1141–1149 8170559
Nortriptyline and fluphenazine in the symptomatic treatment of diabetic neuropathy. A double-blind cross-over study. F. J. Gomez-Perez, J. A. Rull, H. Dies. Pain 1985: 395–400 3911140
Walking performance in people with diabetic neuropathy: benefits and threats. R. V. Kanade, R. W. Deursen, K. Harding, P. Price. Diabetologia 2006: 1747–54 16758177
Impact of glycemic control strategies on the progression of diabetic peripheral neuropathy in the Bypass Angioplasty Revascularization Investigation 2 Diabetes (BARI 2D) Cohort. R. Pop Busui, J. Lu, M. M. Brooks, S. Albert, A. D. Althouse, J. Escobedo, J. Green, P. Palumbo, B. A. Perkins, F. Whitehouse, T. L. Jones. Diabetes Care 2013: 3208–15 23757426
Motor learning of a gait pattern to reduce forefoot plantar pressures in individuals with diabetic peripheral neuropathy. R. M. York, K. L. Perell Gerson, M. Barr, J. Durham, J. M. Roper. PM R 2009: 434–41 19627930
Glucose control and vascular complications in veterans with type 2 diabetes. W. Duckworth, C. Abraira, T. Moritz, D. Reda, N. Emanuele, P. D. Reaven, F. J. Zieve, J. Marks, S. N. Davis, R. Hayward, S. R. Warren, S. Goldman, M. McCarren, M. E. Vitek, W. G. Henderson, G. D. Huang. New England Journal of Medicine 2009: 129–39 19092145
Sodium valproate in the management of painful neuropathy in type 2 diabetes - a randomized placebo controlled study. D. K. Kochar, N. Jain, R. P. Agarwal, T. Srivastava, P. Agarwal, S. Gupta. Acta Neurol Scand 2002: 248–52 12371916
Ganglioside treatment in diabetic peripheral neuropathy: a multicenter trial. G. Crepaldi, D. Fedele, A. Tiengo, L. Battistin, P. Negrin, G. Pozza, N. Canal, G. C. Comi, G. Lenti, G. Pagano. Acta Diabetol Lat 1983: 265–76 6356740
Pregabalin for relief of neuropathic pain associated with diabetic neuropathy: a randomized, double-blind study. T. Tölle, R. Freynhagen, M. Versavel, U. Trostmann, J. P. Young. Eur J Pain 2008: 203–13 17631400
“Mesodiencephalic” modulation in the treatment of diabetic neuropathy. S. Lacigova, J. Tomesova, J. Gruberova, Z. Rusavy, R. Rokyta. Neuro Endocrinol Lett 2013: 135–42 23645311
Zonisamide in the treatment of painful diabetic neuropathy: a randomized, double-blind, placebo-controlled pilot study. A. Atli, S. Dogra. Pain Med 2005: 225–34 15972086
A double-blind, randomized multicenter trial comparing duloxetine with placebo in the management of diabetic peripheral neuropathic pain. J. Raskin, Y. L. Pritchett, F. Wang, D. N. D’Souza, A. L. Waninger, S. Iyengar, J. F. Wernicke. Pain Med 2005: 346–56 16266355
Aldosterone blockade attenuates urinary monocyte chemoattractant protein-1 and oxidative stress in patients with type 2 diabetes complicated by diabetic nephropathy. K. Takebayashi, S. Matsumoto, Y. Aso, T. Inukai. Journal of Clinical Endocrinology and Metabolism 2006: 2214–7 16569732
Treatment of symptomatic diabetic peripheral neuropathy with the protein kinase C beta-inhibitor ruboxistaurin mesylate during a 1-year, randomized, placebo-controlled, double-blind clinical trial. A. I. Vinik, V. Bril, P. Kempler, W. J. Litchy, S. Tesfaye, K. L. Price, E. J. Bastyr. Clin Ther 2005: 1164–80 16199243
Clinical study on the mecobalamin combined with pancreatic kallidinogenase for treatment of diabetic peripheral neuropathy. C. Wang, X. Zhang, J. Du. Pharmaceutical Care and Research 2010: 446–9
Randomized double blind clinical trial: Utilization of umbilical cord blood-derived platelet gel for treatment of diabetic foot ulcers. E. S. Hosseini, A. Goodarzi, B. Molavi, N. Aghdami. Cell Journal 2014: 46–47
Self-care and misplaced confidence: A randomised controlled trial of provision of VibraTip for patients with diabetes at high risk of complications. A. Levy, A. Cole, R. Greenwood. Practical Diabetes 2014: 199–201
Prospective evaluation of the effect of short-term oral vitamin D supplementation on peripheral neuropathy in type 2 diabetes mellitus. D. Shehab, K. Al-Jarallah, N. Abdella, O. A. Mojiminiyi, H. Al Mohamedy. Medical Principles and Practice 2015: 250–6 25720672
Magnetic resonance neurography detects diabetic neuropathy early and with Proximal Predominance. M. Pham, D. Oikonomou, B. Hornung, M. Weiler, S. Heiland, P. Baumer, J. Kollmer, P. P. Nawroth, M. Bendszus. Ann Neurol 2015: 939–48 26381658
Risk factors for lower extremity amputation in patients with diabetic foot ulcers: A hospital-based case-control study. T. G. D. Pemayun, R. M. Naibaho, D. Novitasari, N. Amin, T. T. Minuljo. Diabetic Foot and Ankle 2015:
A randomized controlled trial comparing telemedical and standard outpatient monitoring of diabetic foot ulcers. B. S. B. Rasmussen, J. Froekjaer, M. R. Bjerregaard, J. Lauritsen, J. Hangaard, C. W. Henriksen, U. Halekoh, K. B. Yderstraede. Diabetes Care 2015: 1723–1729 26116717

### Not a RCT or non-randomized with a concurrent comparison group

Pedobarometric evaluation of specific shoe wearing in patients with diabetic peripheral neuropathy. K. Choplin, J. M. Audebrand, B. Beaune. Comput Methods Biomech Biomed Engin 2015: 1902–3 26244483
Near-normoglycaemia and development of neuropathy: a 24-year prospective study from diagnosis of type 1 diabetes. D. Ziegler, M. Behler, M. Schroers-Teuber, M. Roden. BMJ Open 2015: e006559
Resistance exercise training increases lower limb speed of strength generation during stair ascent and descent in people with diabetic peripheral neuropathy. J. C. Handsaker, S. J. Brown, F. L. Bowling, C. N. Maganaris, A. J. Boulton, N. D. Reeves. Diabet Med 2015:
Increased aortic stiffness predicts future development and progression of peripheral neuropathy in patients with type 2 diabetes: the Rio de Janeiro Type 2 Diabetes Cohort Study. C. R. Cardoso, C. B. Moran, F. S. Marinho, M. T. Ferreira, G. F. Salles. Diabetologia 2015: 2161–8 26044207
Effects of Buerger Exercise Combined Health-Promoting Program on Peripheral Neurovasculopathy Among Community Residents at High Risk for Diabetic Foot Ulceration. C. F. Chang, C. C. Chang, S. L. Hwang, M. Y. Chen. Worldviews Evid Based Nurs 2015: 145–53 25963925
Diabetic foot complications and their risk factors from a large retrospective cohort study. K. Al-Rubeaan, M. Al Derwish, S. Ouizi, A. M. Youssef, S. N. Subhani, H. M. Ibrahim, B. N. Alamri. PLoS One 2015: e0124446 25946144
Pilot Study of Exercise Therapy on Painful Diabetic Peripheral Neuropathy. M. Yoo, L. J. D’Silva, K. Martin, N. K. Sharma, M. Pasnoor, J. W. LeMaster, P. M. Kluding. Pain Med 2015: 1482–9 25800666
Radiation therapy for recurrent heterotopic ossification prophylaxis after partial metatarsal amputation. T. J. Boffeli, R. R. Pfannenstein, J. C. Thompson. J Foot Ankle Surg 2015: 345–9 25746770
A cohort study of diabetic patients and diabetic foot ulceration patients in China. Y. Jiang, X. Wang, L. Xia, X. Fu, Z. Xu, X. Ran, L. Yan, Q. Li, Z. Mo, Z. Yan, Q. Ji, Q. Li. Wound Repair Regen 2015: 222–30 25682850
Level of A1C control and its predictors among Lebanese type 2 diabetic patients. H. Noureddine, N. Nakhoul, A. Galal, L. Soubra, M. Saleh. Ther Adv Endocrinol Metab 2014: 43–52 25126407
A novel shear reduction insole effect on the thermal response to walking stress, balance, and gait. J. S. Wrobel, P. Ammanath, T. Le, C. Luring, J. Wensman, G. S. Grewal, B. Najafi, R. Pop-Busui. J Diabetes Sci Technol 2014: 1151–6 25107709
Primary care management of non-institutionalized elderly diabetic patients: The S.AGES cohort - Baseline data. S. Bucher, B. Bauduceau, L. Benattar-Zibi, P. Bertin, G. Berrut, E. Corruble, N. Danchin, T. Delespierre, G. Derumeaux, J. Doucet, B. Falissard, F. Forette, O. Hanon, R. Ourabah, F. Pasquier, C. Piedvache, M. Pinget, V. Ringa, L. Becquemont and S. A. Investigators. Prim Care Diabetes 2015: 267–74 25086913
Rocker outsole shoe is not a threat to postural stability in patients with diabetic neuropathy. B. Ghomian, M. Kamyab, H. Jafari, M. Khamseh, A. Healy. Prosthet Orthot Int 2014:
Severity of demographic and clinical characteristics, revascularization feasibility, major amputation, and mortality rate in diabetic patients admitted to a tertiary diabetic foot center for critical limb ischemia: comparison of 2 cohorts recruited at a 10-year distance. E. Faglia, G. Clerici, A. Scatena, M. Caminiti, V. Curci, M. Prisco, V. Prisco, R. Greco, F. Cetta, A. Morabito. Ann Vasc Surg 2014: 1729–36 24952297
Effect of treatment with sitagliptin on somatosensory-evoked potentials and metabolic control in patients with type 2 diabetes mellitus. J. I. Barros, F. V. Fechine, R. M. Montenegro Junior, O. C. Vale, V. O. Fernandes, M. H. Souza, G. H. Cunha, M. O. Moraes, C. B. d’Alva, M. E. Moraes. Arq Bras Endocrinol Metabol 2014: 369–76 24936731
Diabetic peripheral neuropathy in ambulatory patients with type 2 diabetes in a general hospital in a middle income country: a cross-sectional study. L. Lazo Mde, A. Bernabe-Ortiz, M. E. Pinto, R. Ticse, G. Malaga, K. Sacksteder, J. J. Miranda, R. H. Gilman. PLoS One 2014: e95403 24789071
The role of insulin resistance in diabetic neuropathy in Koreans with type 2 diabetes mellitus: a 6-year follow-up study. Y. N. Cho, K. O. Lee, J. Jeong, H. J. Park, S. M. Kim, H. Y. Shin, J. M. Hong, C. W. Ahn, Y. C. Choi. Yonsei Med J 2014: 700–8 24719137
Exercise-induced modulation of pain in adults with and without painful diabetic neuropathy. M. T. Knauf, K. F. Koltyn. J Pain 2014: 656–63 24632113
Perceived Benefits of Group Exercise Among Individuals With Peripheral Neuropathy. G. Powell-Cope, P. A. Quigley, K. Besterman-Dahan, J. D. Lind. West J Nurs Res 2014: 855–874 24622155
Current glycemic status and diabetes related complications among type 2 diabetes patients in India: data from the A1chieve study. V. Mohan, S. Shah, B. Saboo. J Assoc Physicians India 2013: 12–5
The effectiveness of a single session of Whole-Body Vibration in improving the balance and the strength in type 2 diabetic patients with mild to moderate degree of peripheral neuropathy: a pilot study. A. Kordi Yoosefinejad, A. Shadmehr, G. Olyaei, S. Talebian, H. Bagheri. J Bodyw Mov Ther 2014: 82–6
Balance rehabilitation: promoting the role of virtual reality in patients with diabetic peripheral neuropathy. G. S. Grewal, R. Sayeed, M. Schwenk, M. Bharara, R. Menzies, T. K. Talal, D. G. Armstrong, B. Najafi. J Am Podiatr Med Assoc 2013: 498–507 24297986
Diabetic peripheral neuropathy and gait: does footwear modify this association?. G. S. Grewal, M. Bharara, R. Menzies, T. K. Talal, D. Armstrong, B. Najafi. J Diabetes Sci Technol 2013: 1138–46 24124939
Effects of physical activity on the development and progression of microvascular complications in type 1 diabetes: retrospective analysis of the DCCT study. C. B. Makura, K. Nirantharakumar, A. J. Girling, P. Saravanan, P. Narendran. BMC Endocr Disord 2013: 37 24083407
Complexity-based measures inform Tai Chi’s impact on standing postural control in older adults with peripheral neuropathy. B. Manor, L. A. Lipsitz, P. M. Wayne, C. K. Peng, L. Li. BMC Complement Altern Med 2013: 87 23587193
Observational study of the association of first insulin type in uncontrolled type 2 diabetes with macrovascular and microvascular disease. G. C. Hall, A. D. McMahon, D. Carroll, P. D. Home. PLoS One 2012: e49908 23166795
Area-under-the-HbA1c-curve above the normal range and the prediction of microvascular outcomes: an analysis of data from the Diabetes Control and Complications Trial. L. J. Maple-Brown, C. Ye, R. Retnakaran. Diabet Med 2013: 95–9 22937915
Offloading effect of therapeutic footwear in patients with diabetic neuropathy at high risk for plantar foot ulceration. M. L. Arts, R. Waaijman, M. de Haart, R. Keukenkamp, F. Nollet, S. A. Bus. Diabet Med 2012: 1534–41 22913552
Effect of selected exercises on in-shoe plantar pressures in people with diabetes and peripheral neuropathy. K. M. Shah, M. J. Mueller. Foot (Edinb) 2012: 130–4 22677098
Pressure-reduction and preservation in custom-made footwear of patients with diabetes and a history of plantar ulceration. R. Waaijman, M. L. Arts, R. Haspels, T. E. Busch-Westbroek, F. Nollet, S. A. Bus. Diabet Med 2012: 1542–9 22540919
Dynamic stability training improves standing balance control in neuropathic patients with type 2 diabetes. H. Salsabili, F. Bahrpeyma, B. Forogh, S. Rajabali. J Rehabil Res Dev 2011: 775–86 21938664
Long term Tai Chi exercise improves physical performance among people with peripheral neuropathy. L. Li, B. Manor. Am J Chin Med 2010: 449–59 20503464
Effectiveness of removable walker cast versus nonremovable fiberglass off-bearing cast in the healing of diabetic plantar foot ulcer: a randomized controlled trial. E. Faglia, C. Caravaggi, G. Clerici, A. Sganzaroli, V. Curci, W. Vailati, D. Simonetti, F. Sommalvico. Diabetes Care 2010: 1419–23 20357377
Effect of intensive compared with standard glycemia treatment strategies on mortality by baseline subgroup characteristics: the Action to Control Cardiovascular Risk in Diabetes (ACCORD) trial. J. Calles-Escandon, L. C. Lovato, D. G. Simons-Morton, D. M. Kendall, R. Pop-Busui, R. M. Cohen, D. E. Bonds, V. A. Fonseca, F. Ismail-Beigi, M. A. Banerji, A. Failor, B. Hamilton. Diabetes Care 2010: 721–7 20103550
Long-standing, insulin-treated type 2 diabetes patients with complications respond well to short-term resistance and interval exercise training. S. F. Praet, R. A. Jonkers, G. Schep, C. D. Stehouwer, H. Kuipers, H. A. Keizer, L. J. van Loon. Eur J Endocrinol 2008: 163–72 18230822
Does Tai Chi improve plantar sensory ability? A pilot study. S. Richerson, K. Rosendale. Diabetes Technol Ther 2007: 276–86 17561798
A prospective study of physiotherapist prescribed community based exercise in inflammatory peripheral neuropathy. R. C. Graham, R. A. Hughes, C. M. White. J Neurol 2007: 228–35 17334956
Established diabetic neuropathy seems irreversible despite improvements in metabolic and vascular risk markers--a retrospective case-control study in a hospital patient cohort. D. V. Coppini, M. C. Spruce, P. Thomas, M. G. Masding. Diabet Med 2006: 1016–20 16922709
Frequency of lower extremity amputation in diabetics with reference to glycemic control and Wagner’s grades. S. Imran, R. Ali, G. Mahboob. J Coll Physicians Surg Pak 2006: 124–7 16499806
Potential risk factors for diabetic neuropathy: a case control study. F. Booya, F. Bandarian, B. Larijani, M. Pajouhi, M. Nooraei, J. Lotfi. BMC Neurol 2005: 24 16336693
Glycemic control and the risk of multiple microvascular diabetic complications. K. G. Schellhase, T. D. Koepsell, N. S. Weiss. Fam Med 2005: 125–30 15690253
The acute effects of glycemic control on axonal excitability in human diabetics. Y. Kitano, S. Kuwabara, S. Misawa, K. Ogawara, K. Kanai, Y. Kikkawa, K. Yagui, T. Hattori. Ann Neurol 2004: 462–7 15455400
Interventions improve gait regularity in patients with peripheral neuropathy while walking on an irregular surface under low light. J. K. Richardson, S. B. Thies, T. K. DeMott, J. A. Ashton-Miller. J Am Geriatr Soc 2004: 510–5 15066064
Foot pressures during level walking are strongly associated with pressures during other ambulatory activities in subjects with diabetic neuropathy. K. S. Maluf, R. E. Morley, Jr., E. J. Richter, J. W. Klaesner, M. J. Mueller. Arch Phys Med Rehabil 2004: 253–60 14966710
Postural characteristics of diabetic neuropathy. U. Oppenheim, R. Kohen-Raz, D. Alex, A. Kohen-Raz, M. Azarya. Diabetes Care 1999: 328–32 10333953
Negative association between erythrocyte reduced glutathione concentration and diabetic complications. P. J. Thornalley, A. C. McLellan, T. W. Lo, J. Benn, P. H. Sonksen. Clin Sci (Lond) 1996: 575–82 8942396
Prevalence of diabetic peripheral neuropathy and its relation to glycaemic control and potential risk factors: the EURODIAB IDDM Complications Study. S. Tesfaye, L. K. Stevens, J. M. Stephenson, J. H. Fuller, M. Plater, C. Ionescu-Tirgoviste, A. Nuber, G. Pozza, J. D. Ward. Diabetologia 1996: 1377–84 8933008
The prevalence of neuropathic foot ulceration in Sri Lankan diabetic patients. D. J. Fernando. Ceylon Med J 1996: 96–8 8917968
Postural stability in diabetic polyneuropathy. P. Boucher, N. Teasdale, R. Courtemanche, C. Bard, M. Fleury. Diabetes Care 1995: 638–45 8586001
Are there any glycemic thresholds for the serious microvascular diabetic complications?. P. Reichard. J Diabetes Complications 1995: 25–30 7734740
[Diabetic neuropathy]. M. Ellenberg. Journ Annu Diabetol Hotel Dieu 1976: 59–70 1011427
Prevention of coronary heart disease and stroke complications in type 2 diabetes mellitus: An observational, prospective study. R. M. Ştefan, C. Niţă, A. Crăciun, A. Rusu, N. Hâncu. Romanian Journal of Diabetes, Nutrition and Metabolic Diseases 2015: 175–185
Relationship between β-cell function, metabolic control, and microvascular complications in type 2 diabetes mellitus. L. Zhao, J. Ma, S. Wang, Y. Xie. Diabetes Technology and Therapeutics 2015: 29–34
Macro- and microvascular outcomes in patients with type 2 diabetes treated with rapid-acting insulin analogues or human regular insulin: A retrospective database analysis. W. Rathmann, N. C. Schloot, K. Kostev, M. Reaney, A. J. Zagar, A. Haupt. Experimental and Clinical Endocrinology and Diabetes 2014: 92–99 24558019
Assessment of glycemic control in korean patients with type 2 diabetes mellitus treated with metformin+sulfonylurea: Results of alit study. H. Y. Kim, S. G. Kim, J. R. Hahm, D. K. Kim, S. R. Cho, D. S. Choi. Endocrine Reviews 2013:
A prospective, open-label, multicentre study of pregabalin in the treatment of neuropathic pain in Latin America. M. Xochilcal-Morales, E. M. Castro, J. Guajardo-Rosas, T. N. Obregón, J. C. Acevedo, J. M. G. Chucan, R. Plancarte-Sanchez, G. Davila, D. Wajsbrot, M. Guerrero, R. Vinueza. International Journal of Clinical Practice 2010: 1301–1309 20487048
The role of physical examination in the diagnosis of chronic sensorimotor distal symmetric polyneuropathy in patients with diabetes mellitus. M. Jasik, A. Niebisz, A. Cacko, M. Cenkier, M. Cacko, W. Karnafel. Diabetologia Doswiadczalna i Kliniczna 2009: 17–23
Diabetic neuropathy assessed at two time points five years apart. A. Alajbegovic, S. Alajbegovic, H. Resic. Diabetologia Croatica 2008: 91–96
Relationships between diabetic peripheral neuropathy and affective factors. L. Qin, J. Yin, H. L. Xing. Chinese Journal of Clinical Rehabilitation 2004: 5154–5155
Diabetic neuropathy: Discordance between symptoms and electrophysiological testing in Saudi diabetics. D. H. Akbar. Bahrain Medical Bulletin 2002: 10–12
Clinical characteristics in relation to final amputation level in diabetic patients with foot ulcers: A prospective study of healing below or above the ankle in 187 patients. J. Larsson, C. D. Agardh, J. Apelqvist, A. Stenstrom. Foot and Ankle International 1995: 69–74 7767449
Regression of diabetic neuropathy with total vegetarian (vegan) diet. M. G. Crane, C. Sample. Journal of Nutritional Medicine 1994: 431–439
Management of midfoot diabetic neuroarthropathy. M. S. Myerson, M. R. Henderson, T. Saxby, K. W. Short. Foot and Ankle International 1994: 233–241 7951961
Fractures in the neuropathic diabetic foot. J. Sinha, E. M. Thomas, A. Foster, M. Edmonds. Foot 1994: 28–30
Nortriptyline and fluphenazine in the symptomatic treatment of diabetic neuropathy. A double-blind cross-over study. F. J. Gomez-Perez, J. A. Rull, H. Dies. Pain 1985: 395–400 3911140
Interventions improve gait regularity in patients with peripheral neuropathy while walking on an irregular surface under low light. J. K. Richardson, S. B. Thies, T. K. DeMott, J. A. Ashton Miller. J Am Geriatr Soc 2004: 510–5 15066064
Frequency-modulated electromagnetic neural stimulation enhances cutaneous microvascular flow in patients with diabetic neuropathy. M. Conti, E. Peretti, G. Cazzetta, G. Galimberti, C. Vermigli, R. Pola, L. Scionti, E. Bosi. J Diabetes Complications 2009: 46–8 18403219
The effect of 8 years of strict glycaemic control on peripheral nerve function in IDDM patients: the Oslo Study. K. F. Amthor, K. Dahl J⊘rgensen, T. J. Berg, M. S. Heier, L. Sandvik, O. Aagenaes, K. F. Hanssen. Diabetologia 1994: 579–84 7926342
Evaluation of TCOM/HBOT practice guideline for the treatment of foot burns occurring in diabetic patients. L. M. Jones, C. Rubadue, N. V. Brown, S. Khandelwal, R. A. Coffey. Burns 2015: 536–41 25406882
The use of PriMatrix, a fetal bovine acellular dermal matrix, in healing chronic diabetic foot ulcers: a prospective multicenter study. S. J. Kavros, T. Dutra, R. Gonzalez-Cruz, B. Liden, B. Marcus, J. McGuire, L. Nazario-Guirau. Adv Skin Wound Care 2014: 356–62 25033310
Data-driven directions for effective footwear provision for the high-risk diabetic foot. M. L. Arts, M. de Haart, R. Waaijman, R. Dahmen, H. Berendsen, F. Nollet, S. A. Bus. Diabet Med 2015: 790–7 25763659
The effect of lower extremity nerve decompression on health-related quality of life and perception of pain in patients with painful diabetic polyneuropathy: A prospective randomized trial. J. F. M. Macare van Maurik, R. T. W. Oomen, M. Hal, M. Kon, E. J. G. Peters. Diabetic Medicine 2015: 803–9
Effects of a Novel Therapeutic Intervention in Patients with Diabetic Peripheral Neuropathy. A. Alshahrani, M. Bussell, E. Johnson, B. Tsao, K. Bahjri. Arch Phys Med Rehabil 2016: 733–738 26808781
Microsurgical Reconstruction of Plantar Ulcers of the Insensate Foot. D. Kadam. J Reconstr Microsurg 2016:
Effects of Buerger Exercise Combined Health-Promoting Program on Peripheral Neurovasculopathy Among Community Residents at High Risk for Diabetic Foot Ulceration. C. F. Chang, C. C. Chang, S. L. Hwang, M. Y. Chen. Worldviews Evid Based Nurs 2015: 145–153 25963925
Safety of aerobic exercise in people with diabetic peripheral neuropathy: single-group clinical trial. P. M. Kluding, M. Pasnoor, R. Singh, L. J. D’Silva, M. Yoo, S. A. Billinger, J. W. LeMaster, M. M. Dimachkie, L. Herbelin, D. E. Wright. Phys Ther 2015: 223–234 25278335

### Addresses KQ2a &b (treating symptoms of diabetic neuropathy) only

The Diabetes Visual Function Supplement Study (DiVFuSS). A. P. Chous, S. P. Richer, J. D. Gerson, R. A. Kowluru. Br J Ophthalmol 2015:
Stratified analyses for selecting appropriate target patients with diabetic peripheral neuropathy for long-term treatment with an aldose reductase inhibitor, epalrestat. N. Hotta, R. Kawamori, Y. Atsumi, M. Baba, H. Kishikawa, J. Nakamura, S. Oikawa, N. Yamada, H. Yasuda, Y. Shigeta and A. S. Group. Diabet Med 2008: 818–25 18644069
Therapeutic efficacy of ozone in patients with diabetic foot. G. Martinez-Sanchez, S. M. Al-Dalain, S. Menendez, L. Re, A. Giuliani, E. Candelario-Jalil, H. Alvarez, J. I. Fernandez-Montequin, O. S. Leon. Eur J Pharmacol 2005: 151–61
Randomized double-blind study comparing the efficacy of gabapentin with amitriptyline on diabetic peripheral neuropathy pain. C. M. Morello, S. G. Leckband, C. P. Stoner, D. F. Moorhouse, G. A. Sahagian. Arch Intern Med 1999: 1931–7 10493324
Effect of 24 weeks of treatment with epalrestat, an aldose reductase inhibitor, on peripheral neuropathy in patients with non-insulin-dependent diabetes mellitus. K. Uchida, T. Kigoshi, S. Nakano, T. Ishii, M. Kitazawa, S. Morimoto. Clin Ther 1995: 460–6 7585850
Capsaicin 8% patch repeat treatment versus standard of care in painful diabetic peripheral neuropathy: A randomised, open-label, 52-week study. A. I. Vinik, S. Perrot, E. J. Vinik, L. Pazdera, H. Jacobs, M. Stoker, S. Long, R. Snijder, M. Van Der Stoep, E. Ortega, N. Katz. Diabetologia 2015: S514–S515
Pregabalin positively affects subjective pain, falls risk, and gait in persons with diabetic peripheral neuropathy. S. Morrison, H. Parson, A. I. Vinik. Diabetes 2015: A164
A randomized, single-blind, controlled, parallel assignment study of exercise versus education as adjuvant in the treatment of peripheral neuropathic pain. C. Toth, S. Brady, F. Gagnon, K. Wigglesworth. Clinical Journal of Pain 2014: 111–118 23887332
Effect of 12 week yoga therapy as a lifestyle intervention in patients of type 2 diabetes mellitus with distal symmetric polyneuropathy. S. Nishanth, T. Madanmohan, A. K. Das, T. Ramkumar, S. Senthilkumar. Indian Journal of Physiology and Pharmacology 2011: 64
Efficacy of Pregabalin for Peripheral Neuropathic Pain: Results of an 8-Week, Flexible-Dose, Double-Blind, Placebo-Controlled Study Conducted in China. Y. Guan, X. Ding, Y. Cheng, D. Fan, L. Tan, Y. Wang, Z. Zhao, Z. Hong, D. Zhou, X. Pan, S. Chen, A. Martin, H. Tang, L. Cui. Clinical Therapeutics 2011: 159–166 21444113
The effect of prostaglandin E1αCD on vibratory threshold determined with the SMV-5 vibrometer in patients with diabetic neuropathy. H. Shindo, M. Tawata, M. Inoue, N. Yokomori, Y. Hosaka, M. Ohtaka, T. Onaya. Diabetes Research and Clinical Practice 1994: 173–180 7988349
The Sorbinil Retinopathy Trial: Neuropathy results. S. Carlison, W. Coles, D. Costigan, L. Curtis, E. Hedaya, D. Klements, T. Meredith, P. Sternberg Jr, R. Swords, J. Belt, D. Cornblath, A. Georgopoulis, J. Griffin, R. Murphy, D. Rytel, C. Saudek, J. Carl, P. Ciatto, D. Seigel. Neurology 1993: 1141–1149 8170559
Sodium valproate in the management of painful neuropathy in type 2 diabetes - a randomized placebo controlled study. D. K. Kochar, N. Jain, R. P. Agarwal, T. Srivastava, P. Agarwal, S. Gupta. Acta Neurol Scand 2002: 248–52 12371916
Ganglioside treatment in diabetic peripheral neuropathy: a multicenter trial. G. Crepaldi, D. Fedele, A. Tiengo, L. Battistin, P. Negrin, G. Pozza, N. Canal, G. C. Comi, G. Lenti, G. Pagano. Acta Diabetol Lat 1983: 265–76 6356740
Pregabalin for relief of neuropathic pain associated with diabetic neuropathy: a randomized, double-blind study. T. Tölle, R. Freynhagen, M. Versavel, U. Trostmann, J. P. Young. Eur J Pain 2008: 203–13 17631400
“Mesodiencephalic” modulation in the treatment of diabetic neuropathy. S. Lacigova, J. Tomesova, J. Gruberova, Z. Rusavy, R. Rokyta. Neuro Endocrinol Lett 2013: 135–42 23645311
Zonisamide in the treatment of painful diabetic neuropathy: a randomized, double-blind, placebo-controlled pilot study. A. Atli, S. Dogra. Pain Med 2005: 225–34 15972086
A double-blind, randomized multicenter trial comparing duloxetine with placebo in the management of diabetic peripheral neuropathic pain. J. Raskin, Y. L. Pritchett, F. Wang, D. N. D’Souza, A. L. Waninger, S. Iyengar, J. F. Wernicke. Pain Med 2005: 346–56 16266355
Effect of intravenous versus subcutaneous insulin delivery on the intensity of neuropathic pain in diabetic subjects. D. Rokicka, M. Wrobel, A. Szymborska Kajanek, M. Adamczyk Sowa, A. Bozek, K. Pierzchala, K. Strojek. Endokrynol Pol 2015: 237–43 26136133
The effect of lower extremity nerve decompression on health-related quality of life and perception of pain in patients with painful diabetic polyneuropathy: A prospective randomized trial. J. F. M. Macare van Maurik, R. T. W. Oomen, M. Hal, M. Kon, E. J. G. Peters. Diabetic Medicine 2015: 803–9
Effects of exenatide on measures of diabetic neuropathy in subjects with type 2 diabetes: Results from an 18-month proof-of-concept open-label randomized study. M. Jaiswal, C. L. Martin, M. B. Brown, B. Callaghan, J. W. Albers, E. L. Feldman, R. Pop-Busui. J Diabetes Complications 2015: 1287–1294 26264399

### Not all patients have diabetes in both group

Effect of Tai Chi Exercise Combined with Mental Imagery Theory in Improving Balance in a Diabetic and Elderly Population. A. Alsubiheen, J. Petrofsky, N. Daher, E. Lohman, E. Balbas. Med Sci Monit 2015: 3054–61 26454826
Relationship between glycemic control, microalbuminuria and cognitive functions in elderly type 2 diabetic patients. C. B. Gul, O. Oz Gul, S. Cander, A. Eroglu, M. Hartavi, N. Keni, A. Bayindir, C. Ersoy, E. Erturk, E. Tuncel, S. Imamoglu. Ren Fail 2014: 1258–62 25020185
Exercise improves gait, reaction time and postural stability in older adults with type 2 diabetes and neuropathy. S. Morrison, S. R. Colberg, H. K. Parson, A. I. Vinik. J Diabetes Complications 2014: 715–22 24929798
Windlass Mechanism in Individuals With Diabetes Mellitus, Peripheral Neuropathy, and Low Medial Longitudinal Arch Height. J. R. Gelber, D. R. Sinacore, M. J. Strube, M. J. Mueller, J. E. Johnson, F. W. Prior, M. K. Hastings. Foot Ankle Int 2014: 816–824 24917647
Exercise-induced modulation of pain in adults with and without painful diabetic neuropathy. M. T. Knauf, K. F. Koltyn. J Pain 2014: 656–63 24632113
Diabetic peripheral neuropathy and gait: does footwear modify this association?. G. S. Grewal, M. Bharara, R. Menzies, T. K. Talal, D. Armstrong, B. Najafi. J Diabetes Sci Technol 2013: 1138–46 24124939
The impact of footwear and walking distance on gait stability in diabetic patients with peripheral neuropathy. B. Najafi, T. Khan, A. Fleischer, J. Wrobel. J Am Podiatr Med Assoc 2013: 165–73 23697719
Do diabetic neuropathy patients benefit from balance training?. M. Akbari, H. Jafari, A. Moshashaee, B. Forugh. J Rehabil Res Dev 2012: 333–8 22773533
Ankle and hindfoot fusions: comparison of outcomes in patients with and without diabetes. T. G. Myers, N. J. Lowery, R. G. Frykberg, D. K. Wukich. Foot Ankle Int 2012: 20–8 22381232
Functional balance in elderly with diabetic neuropathy. T. Ghanavati, M. J. Shaterzadeh Yazdi, S. Goharpey, A. A. Arastoo. Diabetes Res Clin Pract 2012: 24–8
Lower extremity muscle strength is reduced in people with type 2 diabetes, with and without polyneuropathy, and is associated with impaired mobility and reduced quality of life. I. J. TH, N. C. Schaper, T. Melai, K. Meijer, P. J. Willems, H. H. Savelberg. Diabetes Res Clin Pract 2012: 345–51 22104262
Effect of 12-week tai chi chuan exercise on peripheral nerve modulation in patients with type 2 diabetes mellitus. J. W. Hung, C. W. Liou, P. W. Wang, S. H. Yeh, L. W. Lin, S. K. Lo, F. M. Tsai. J Rehabil Med 2009: 924–9 19841845
A prospective study of physiotherapist prescribed community based exercise in inflammatory peripheral neuropathy. R. C. Graham, R. A. Hughes, C. M. White. J Neurol 2007: 228–35 17334956
Diabetes, peripheral neuropathy, and old age disability. H. E. Resnick, K. B. Stansberry, T. B. Harris, M. Tirivedi, K. Smith, P. Morgan, A. I. Vinik. Muscle Nerve 2002: 43–50 11754184
Timing of peak plantar pressure during the stance phase of walking. A study of patients with diabetes mellitus and transmetatarsal amputation. V. E. Kelly, M. J. Mueller, D. R. Sinacore. J Am Podiatr Med Assoc 2000: 18–23 10659528
Postural characteristics of diabetic neuropathy. U. Oppenheim, R. Kohen-Raz, D. Alex, A. Kohen-Raz, M. Azarya. Diabetes Care 1999: 328–32 10333953
An analysis of dynamic forces transmitted through the foot in diabetic neuropathy. J. E. Shaw, C. H. van Schie, A. L. Carrington, C. A. Abbott, A. J. Boulton. Diabetes Care 1998: 1955–9 9802750
Aerobic exercise capacity remains normal despite impaired endothelial function in the micro- and macrocirculation of physically active IDDM patients. A. Veves, R. Saouaf, V. M. Donaghue, C. A. Mullooly, J. A. Kistler, J. M. Giurini, E. S. Horton, R. A. Fielding. Diabetes 1997: 1846–52 9356035
Negative association between erythrocyte reduced glutathione concentration and diabetic complications. P. J. Thornalley, A. C. McLellan, T. W. Lo, J. Benn, P. H. Sonksen. Clin Sci (Lond) 1996: 575–82 8942396
Postural rearrangement in IDDM patients with peripheral neuropathy. P. G. Giacomini, E. Bruno, G. Monticone, S. Di Girolamo, A. Magrini, L. Parisi, G. Menzinger, L. Uccioli. Diabetes Care 1996: 372–4 8729163
Postural stability in diabetic polyneuropathy. P. Boucher, N. Teasdale, R. Courtemanche, C. Bard, M. Fleury. Diabetes Care 1995: 638–45 8586001
Effect of intensive diabetes management on macrovascular events and risk factors in the Diabetes Control and Complications Trial.. Am J Cardiol 1995: 894–903 7732997
Gait characteristics in patients with type 2 diabetes; improvement after administration of rosiglitazone. J. S. Petrofsky, S. Lee, M. L. Cuneo. Medical Science Monitor 2005: PI43–PI51 15917728
Interventions improve gait regularity in patients with peripheral neuropathy while walking on an irregular surface under low light. J. K. Richardson, S. B. Thies, T. K. DeMott, J. A. Ashton Miller. J Am Geriatr Soc 2004: 510–5 15066064
Step length after discrete perturbation predicts accidental falls and fall-related injury in elderly people with a range of peripheral neuropathy. L. Allet, H. Kim, J. Ashton Miller, T. Mott, J. K. Richardson. J Diabetes Complications 2014: 79–84 24183899

### Other reasons

The association of physical activity and diabetic complications in individuals with insulin-dependent diabetes mellitus: the Epidemiology of Diabetes Complications Study--VII. A. M. Kriska, R. E. LaPorte, S. L. Patrick, L. H. Kuller, T. J. Orchard. J Clin Epidemiol 1991: 1207–14 1941015
[Staging-syndrome differentiation in treating diabetic foot disorder and its effect on hemodynamic changes of lower extremities with arterial ultrasonic Doppler diagnostic apparatus]. G. Fan, R. Lu. Zhongguo Zhong Xi Yi Jie He Za Zhi 1999: 520–3 11783182
[Diabetic neuropathy: thermal sensation and metabolic control in non-insulin-dependent diabetics]. P. Olmos, L. Camilla, P. Mellado, P. Moya, P. Arriagada, M. Jimenez, A. Maiz, A. Arteaga, N. Velasco, A. M. Acosta, M. Escalona, M. Borcoski. Rev Med Chil 1997: 1319–27 9609053
[Unbalanced diet behind the epidemic on Cuba. Smoking as a risk factor of optic neuropathy]. H. Rosling. Lakartidningen 1994: 4018–9 7967978
[Diabetic neuropathy]. M. Ellenberg. Journ Annu Diabetol Hotel Dieu 1976: 59–70 1011427
Effects of 12-weeks combined trainings with vitamin D supplement on the sensory-motor neuropathy in women with type 2 diabetes. M. Nadi, S. M. Marandi, F. Esfarjani, M. Mohammadi, F. Ahmadi. Journal of Isfahan Medical School 2015: 1–9
Determination of the the effectiveness of home exercise program in patients with diabetic neuropathy,Diyabetik Noropatili Hastalarda Ev Egzersiz Programinin Etkinlitinin Belirlenmesi. [Turkish]. L. Cerrahotlu, U. Kosan, E. Topcu. Turkiye Fiziksel Tip ve Rehabilitasyon Dergisi 2013: 359
Clinical study on the mecobalamin combined with pancreatic kallidinogenase for treatment of diabetic peripheral neuropathy. C. Wang, X. Zhang, J. Du. Pharmaceutical Care and Research 2010: 446–9
Perceived Benefits of Group Exercise Among Individuals With Peripheral Neuropathy. G. Powell-Cope, P. A. Quigley, K. Besterman-Dahan, J. D. Lind. West J Nurs Res 2014: 855–874 24622155
Effects of a combined strengthening, stretching and functional training program versus usual-care on gait biomechanics and foot function for diabetic neuropathy: a randomized controlled trial. C. D. Sartor, R. Watari, A. C. Passaro, A. P. Picon, R. H. Hasue, I. C. Sacco. BMC Musculoskelet Disord 2012: 36 22429765
C-peptide replacement therapy and sensory nerve function in type 1 diabetic neuropathy. K. Ekberg, T. Brismar, B. L. Johansson, P. Lindström, L. Juntti-Berggren, A. Norrby, C. Berne, H. J. Arnqvist, J. Bolinder, J. Wahren. Diabetes Care 2007: 71–76 17192336
Assessment of the rocker sole shoes on postural stability in diabetic patients with distal sensory neuropathy. M. Lumeau, M. Lempereur, O. Remy-Neris. Comput Methods Biomech Biomed Engin 2015: 1986–7 26269202
Complexity-based measures inform Tai Chi’s impact on standing postural control in older adults with peripheral neuropathy. B. Manor, L. A. Lipsitz, P. M. Wayne, C. K. Peng, L. Li. BMC Complement Altern Med 2013: 87 23587193
Hip and ankle walking strategies: effect on peak plantar pressures and implications for neuropathic ulceration. M. J. Mueller, D. R. Sinacore, S. Hoogstrate, L. Daly. Arch Phys Med Rehabil 1994: 1196–200 7979928
Effects of beta-adrenoceptor agonists and antagonists in patients with peripheral autonomic neuropathy. A. J. Man in’t Veld, F. Boomsma, M. A. Schalekamp. Br J Clin Pharmacol 1982: 367S–374S 6125189
Botulinum toxin effects on gasatrocnemius strength and plantar pressure in diabetics with peripheral neuropathy and forefoot ulceration. M. K. Hastings, M. J. Mueller, D. R. Sinacore, M. J. Strube, B. E. Crowner, J. E. Johnson, B. R. Racette. Foot Ankle Int 2012: 363–70 22735277
A pilot study of intranasal insulin for the treatment of diabetic peripheral neuropathy. L. Korngut, S. Mawani, G. Francis, E. Mehina, B. Hemmelgarn, N. Jette, D. W. Zochodne, S. Wiebe, C. Toth. Journal of the Peripheral Nervous System 2013: S59
Effect of intravenous versus subcutaneous insulin delivery on the intensity of neuropathic pain in diabetic subjects. D. Rokicka, M. Wrobel, A. Szymborska Kajanek, M. Adamczyk Sowa, A. Bozek, K. Pierzchala, K. Strojek. Endokrynol Pol 2015: 237–43 26136133
A pilot study evaluating non-contact low-frequency ultrasound and underlying molecular mechanism on diabetic foot ulcers. M. Yao, H. Hasturk, A. Kantarci, G. Gu, S. Garcia-Lavin, M. Fabbi, N. Park, H. Hayashi, K. Attala, M. A. French, V. R. Driver. Int Wound J 2014: 586–593 23163982
The Diabetes Visual Function Supplement Study (DiVFuSS). A. P. Chous, S. P. Richer, J. D. Gerson, R. A. Kowluru. Br J Ophthalmol 2015:
Long-term effects of goshajinkigan in prevention of diabetic complications: a randomized open-labeled clinical trial. K. Watanabe, A. Shimada, K. Miyaki, A. Hirakata, K. Matsuoka, K. Omae, I. Takei. Evid Based Complement Alternat Med 2014: 128726 24812564

## KQ2 Excluded Articles

### No original data/No full report

Electroacupuncture to treat painful diabetic neuropathy: study protocol for a three-armed, randomized, controlled pilot trial. S. Lee, J. H. Kim, K. M. Shin, J. E. Kim, T. H. Kim, K. W. Kang, M. Lee, S. Y. Jung, M. S. Shin, A. R. Kim, H. J. Park, K. E. Hong, S. M. Choi. Trials 2013: 225 23866906
Take a seat. L. Wahowiak. Diabetes Forecast 2014: 32–4
Metabolic and compressive neuropathy. S. L. Barrett, A. L. Dellon, J. Fleischli, J. S. Gould, C. Wang. Foot Ankle Spec 2010: 132–9 20508014
Population pharmacokinetic/pharmacodynamic models for duloxetine in the treatment of diabetic peripheral neuropathic pain. E. Yuen, I. Gueorguieva, L. Bueno-Burgos, S. Iyengar, L. Aarons. Eur J Pain 2013: 382–93 22893563
Capsaicin 8% patch in painful diabetic peripheral neuropathy: A randomised, double-blind, placebo-controlled study. M. Stoker, N. Katz, J. Van, R. Snijder, H. Jacobs, S. Long, D. Schregardus, B. Lambourg, J. Robinson-Papp, D. Simpson. Diabetologia 2015: S32
Pregabalin positively affects subjective pain, falls risk, and gait in persons with diabetic peripheral neuropathy. S. Morrison, H. Parson, A. I. Vinik. Diabetes 2015: A164
Ds-5565 for the treatment of diabetic peripheral neuropathic pain: Randomized, double-blind, placebo- and active comparator-controlled phase ii study. A. Vinik, U. Sharma, K. Feins, C. Hsu, D. Merante. Neurology 2014: #Pages#
Peripheral edema and weight gain in adult patients with painful diabetic peripheral neuropathy (DPN) receiving gabapentin enacarbil (GEN) or pregabalin enrolled in a randomized phase 2 trial. A. Calkins, J. Shurman, M. Jaros, R. Kim, G. Shang. Neurology 2014: #Pages#
Evaluation of efficacy of duloxetine and pregabalin in patients with painful diabetic peripheral neuropathy. P. Rahimzadeh, S. Faiz, F. Imani, M. Alebouyeh. Journal of Pain 2014: S72
Botulinum toxin type (A) in severe diabetic neuropathy: Double blind cross study. M. Goma, H. Egila, A. Abdel-Naby. J Neurol Sci 2013: e534
Effect of smoked cannabis on painful diabetic peripheral neuropathy. M. Wallace, J. Atkinson, B. Gouaux, T. Marcotte, A. Umlauf. Journal of Pain 2013: S62
Efficacy and tolerability of tapentadol extended release (ER) in patients with chronic, painful diabetic peripheral neuropathy (DPN): Results of a phase 3, randomized-withdrawal, placebo-controlled study. A. Vinik, D. Y. Shapiro, C. Rauschkolb, B. Lange, K. Karcher, D. Pennett, M. S. Etropolski. Reg Anesth Pain Med 2013: #Pages#
Initial treatment with duloxetine or pregabaline in patients with painful diabetic neuropathy. Data from the randomised, double-blind, parallelgroup COMBO-DN Study. S. Wilhelm, T. Tölle, D. Bouhassira, S. Perrot, E. Kosek, J. A. Micó, A. Lledo, R. Freynhagen, G. Cruccu, M. Späth, V. Skljarevski, A. Schacht, S. Tesfaye. Diabetologia 2012: S25–S26
Gabapentin/vitamins B1/B12: An efficacious and safe combination for painful diabetic peripheral neuropathy control. M. Alpizar, A. J. Mimenza, R. A. Olivares, G. Villalpando, S. G. Aguilar, A. Aguilar, A. G. Garcia, A. Torres. Diabetologia 2012: S479–S480
Non-pharmacological treatment of diabetic polyneuropathy by pulse electromagnetic field. V. B. Mirkovic, L. Banjac, Z. Dasic, M. Dapcevic. HealthMED 2012: 1291–1295
The role of acupuncture in the management of painful diabetic neuropathy (PDN): A randomized clinical trial. A. Garrow, M. Xing, J. Vere, B. Verrall, L. Wang, E. Jude. Diabetes 2012: A153
The effect of H-coil repetitive transcranial magnetic stimulation on painful diabetic neuropathy: A randomized placebo-controlled crossover study. E. Onesti, G. Tartaglia, M. Gabriele, F. Gilio, V. Frasca, F. Pichiorri, E. Giacomelli, C. Cambieri, M. Ceccanti, R. Raccah, A. Zangen, M. Inghilleri. Journal of the Peripheral Nervous System 2012: S41
Combined therapy of pain syndromes in diabetic neuropathy. O. Zagorulko, A. Gnezdilov, L. Medvedeva, N. Samoylova. Eur J Anaesthesiol 2011: 204
Combination of the back-shu points and the fron-mu points for nerve conduction velocity of patients with diabetic peripheral neuropathy. X. R. Wang, M. H. Lu, W. L. Li, D. A. Zhou. Chinese Journal of Clinical Rehabilitation 2005: 148–149
Effect of acupuncture treatment on peripheral nerve disease due to type 2 diabetes mellitus and serum glucagon. P. Ding, J. F. Shen, Y. Y. Luo, P. Yang. Chinese Journal of Clinical Rehabilitation 2004: 2872–2873
Photon stimulation: A new form of therapy for chronic diabetic painful neuropathy of the feet. J. Green, E. Horowitz, D. Fralicker, W. Clewell, G. Ossi, M. Briley, T. Lucey. Pain Digest 1999: 286–291
Alpha-lipoic acid in the treatment of autonomic diabetic neuropathy (controlled, randomized, open-label study). T. Tankova, D. Koev, L. Dakovska. Rom J Intern Med 2004: 457–64 15529636
Alpha-lipoic acid improves peripheral insulin sensitivity in patients with type 2 diabetes. P. Kamenova, D. Koev, L. Dakovska, G. Kirilov, A. Nicheva. Endocrinologia 2002: 19–24
Alpha-lipoic acid in the treatment of diabetic peripheral and cardiac autonomic neuropathy. D. Ziegler, F. A. Gries. Diabetes 1997: S62–6 9285502
Treatment for chronic pain syndrome of diabetic peripheral neuropathy in type 2 diabetics with thioctic acid and standardised protein-free dialysate of calf blood. L. A. Ivanova, O. N. Rostovtseva. Diabetologia 2013: S498
Efficacy of alpha-lipoic acid in the treatment of diabetic polyneuropathy. A randomized, double blind study. R. O. Millan Guerrero, A. Garcia Ramirez, O. Gonzalez Perez, B. Trujillo Hernandez, S. Isais Millan, F. J. Castillo Varela. Neurology 2012: #Pages#
Oral alpha-lipoic acid combined with methylcobalamin in treatment of diabetic peripheral neuropathy. L. Qin, X. Y. Li, Q. Su, Z. M. Liu. Academic Journal of Second Military Medical University 2013: 306–9
High dose long term treatment with thioctic acid in diabetic polyneuropathy: results of a controlled randomised study with particular attention on autonomic neuropathy. B. Reschke, S. Zeuzem, C. Rosak, R. Petzoldt, P. H. Althoff, H. Ulrich. Thioctsaure: Neue Biochemische, Pharmakologische Und Klinische Erkenntnisse Zur Thioctsaure 1989: 318–34
Effect of 12 week yoga therapy as a lifestyle intervention in patients of type 2 diabetes mellitus with distal symmetric polyneuropathy. S. Nishanth, T. Madanmohan, A. K. Das, T. Ramkumar, S. Senthilkumar. Indian J Physiol Pharmacol 2011: 64
Capsaicin 8% patch repeat treatment versus standard of care in painful diabetic peripheral neuropathy: A randomised, open-label, 52-week study. A. I. Vinik, S. Perrot, E. J. Vinik, L. Pazdera, H. Jacobs, M. Stoker, S. Long, R. Snijder, M. Van Der Stoep, E. Ortega, N. Katz. Diabetologia 2015: S514–S5
Increasing bioavailability of (R)-alpha-lipoic acid to boost antioxidant activity in the treatment of neuropathic pain. E. Maglione, C. Marrese, E. Migliaro, F. Marcuccio, C. Panico, C. Salvati, G. Citro, M. Quercio, F. Roncagliolo, C. Torello, M. Brufani. Acta Biomed 2015: 226–33 26694149
Botulinum toxin type a in severe diabetic neuropathy. M. Gomaa, H. Egila, A. A. El-Naby, M. Shehab-Eldin. Neurology 2016: #Pages#
Tapentadol prolonged release in the treatment of neuropathic pain related to diabetic polyneuropathy. C. Elling, M. Galic, I. Steigerwald. The Lancet Neurology 2015: 684–685

### Not evaluating people with type 1 or type 2 diabetes with peripheral polyneuropathy

Exercise-induced modulation of pain in adults with and without painful diabetic neuropathy. M. T. Knauf, K. F. Koltyn. J Pain 2014: 656–63 24632113
Electroacupuncture is not effective in chronic painful neuropathies. P. Penza, M. Bricchi, A. Scola, A. Campanella, G. Lauria. Pain Med 2011: 1819–23 21917117
Alpha-lipoic acid in the treatment of autonomic diabetic neuropathy (controlled, randomized, open-label study). T. Tankova, D. Koev, L. Dakovska. Rom J Intern Med 2004: 457–64 15529636
Effects of treatment with the antioxidant α-lipoic acid on cardiac autonomic neuropathy in NIDDM patients: A 4-month randomized controlled multicenter trial (DEKAN study). D. Ziegler, H. Schatz, F. Conrad, F. A. Gries, H. Ulrich, G. Reichel. Diabetes Care 1997: 369–373 9051389
A double-blind, randomized, placebo-controlled, parallel group study of THC/CBD spray in peripheral neuropathic pain treatment. M. Serpell, S. Ratcliffe, J. Hovorka, M. Schofield, L. Taylor, H. Lauder, E. Ehler. Eur J Pain 2014: 999–1012 24420962

### Not all patients have diabetes in either group

Syncardial massage in diabetic and other neuropathies of lower extremities. E. J. Valtonen, H. G. Lilius. Dis Nerv Syst 1973: 192–4
A randomized, single-blind, controlled, parallel assignment study of exercise versus education as adjuvant in the treatment of peripheral neuropathic pain. C. Toth, S. Brady, F. Gagnon, K. Wigglesworth. Clinical Journal of Pain 2014: 111–118 23887332
Efficacy of pregabalin for peripheral neuropathic pain: results of an 8-week, flexible-dose, double-blind, placebo-controlled study conducted in China. Y. Guan, X. Ding, Y. Cheng, D. Fan, L. Tan, Y. Wang, Z. Zhao, Z. Hong, D. Zhou, X. Pan, S. Chen, A. Martin, H. Tang, L. Cui. Clin Ther 2011: 159–66 21444113

### Not a parallel or crossover randomized controlled trials

Exercise-induced modulation of pain in adults with and without painful diabetic neuropathy. M. T. Knauf, K. F. Koltyn. J Pain 2014: 656–63 24632113
Evaluation of the clinical efficacy of multiple lower extremity nerve decompression in diabetic peripheral neuropathy. W. Zhang, S. Li, X. Zheng. J Neurol Surg A Cent Eur Neurosurg 2013: 96–100 23250876
A highly successful and novel model for treatment of chronic painful diabetic peripheral neuropathy. M. A. Pfeifer, D. R. Ross, J. P. Schrage, D. A. Gelber, M. P. Schumer, G. M. Crain, S. J. Markwell, S. Jung. Diabetes Care 1993: 1103–15 8375240
Syncardial massage in diabetic and other neuropathies of lower extremities. E. J. Valtonen, H. G. Lilius. Dis Nerv Syst 1973: 192–4
Decompression of multiple peripheral nerves in the treatment of diabetic neuropathy: A prospective, blinded study. O. C. Aszmann, A. Lee Dellon. Acta Chirurgica Austriaca 2001: 117–120
Photon stimulation: A new form of therapy for chronic diabetic painful neuropathy of the feet. J. Green, E. Horowitz, D. Fralicker, W. Clewell, G. Ossi, M. Briley, T. Lucey. Pain Digest 1999: 286–291
Increasing bioavailability of (R)-alpha-lipoic acid to boost antioxidant activity in the treatment of neuropathic pain. E. Maglione, C. Marrese, E. Migliaro, F. Marcuccio, C. Panico, C. Salvati, G. Citro, M. Quercio, F. Roncagliolo, C. Torello, M. Brufani. Acta Biomed 2015: 226–33 26694149

### No outcome of interest

A novel plantar stimulation technology for improving protective sensation and postural control in patients with diabetic peripheral neuropathy: a double-blinded, randomized study. B. Najafi, R. T. Crews, J. S. Wrobel. Gerontology 2013: 473–80 23860103
How do changes in pain severity levels correspond to changes in health status and function in patients with painful diabetic peripheral neuropathy?. D. L. Hoffman, A. Sadosky, E. M. Dukes, J. Alvir. Pain 2010: 194–201
OnabotulinumtoxinA improves tactile and mechanical pain perception in painful diabetic polyneuropathy. W. T. Chen, R. Y. Yuan, S. C. Chiang, J. J. Sheu, J. M. Yu, I. J. Tseng, S. K. Yang, H. H. Chang, C. J. Hu. Clin J Pain 2013: 305–10 23462284
Decompression of multiple peripheral nerves in the treatment of diabetic neuropathy: A prospective, blinded study. O. C. Aszmann, A. Lee Dellon. Acta Chirurgica Austriaca 2001: 117–120
A novel plantar stimulation technology for improving protective sensation and postural control in patients with diabetic peripheral neuropathy: A double-blinded, randomized study. B. Najafi, R. T. Crews, J. S. Wrobel. Gerontology 2014: 473–80
Predictors of improvement and progression of diabetic polyneuropathy following treatment with alpha-lipoic acid for 4 years in the NATHAN 1 trial. D. Ziegler, P. A. Low, R. Freeman, H. Tritschler, A. I. Vinik. J Diabetes Complications 2016: 350–6 26651260

### Drug/non-pharmacological interventions are not available

Efficacy and safety of recombinant human nerve growth factor in patients with diabetic polyneuropathy: A randomized controlled trial. rhNGF Clinical Investigator Group. S. C. Apfel, S. Schwartz, B. T. Adornato, R. Freeman, V. Biton, M. Rendell, A. Vinik, M. Giuliani, J. C. Stevens, R. Barbano, P. J. Dyck. JAMA 2000: 2215–21 11056593
Assessment of antioxidant supplementation on the neuropathic pain score and quality of life in diabetic neuropathy patients - a randomized controlled study. M. G. Rajanandh, S. Kosey, G. Prathiksha. Pharmacol Rep 2014: 44–8
Efficacy and safety of dextromethorphan/quinidine at two dosage levels for diabetic neuropathic pain: a double-blind, placebo-controlled, multicenter study. A. I. Shaibani, L. E. Pope, R. Thisted, A. Hepner. Pain Med 2012: 243–54
Ds-5565 for the treatment of diabetic peripheral neuropathic pain: Randomized, double-blind, placebo- and active comparator-controlled phase ii study. A. Vinik, U. Sharma, K. Feins, C. Hsu, D. Merante. Neurology 2014: #Pages#
Effect of intravenous versus subcutaneous insulin delivery on the intensity of neuropathic pain in diabetic subjects. D. Rokicka, M. Wrobel, A. Szymborska Kajanek, M. Adamczyk Sowa, A. Bozek, K. Pierzchala, K. Strojek. Endokrynol Pol 2015: 237–43 26136133

### Not relevant to key questions

Ultrasound findings after surgical decompression of the tarsal tunnel in patients with painful diabetic polyneuropathy: a prospective randomized study. J. F. Macare van Maurik, M. E. Schouten, I. ten Katen, M. van Hal, E. J. Peters, M. Kon. Diabetes Care 2014: 767–72 24379356
How do changes in pain severity levels correspond to changes in health status and function in patients with painful diabetic peripheral neuropathy?. D. L. Hoffman, A. Sadosky, E. M. Dukes, J. Alvir. Pain 2010: 194–201
Non-pharmacological treatment of diabetic polyneuropathy by pulse electromagnetic field. V. B. Mirkovic, L. Banjac, Z. Dasic, M. Dapcevic. HealthMED 2012: 1291–1295
Treatment of diabetic polyneuropathy with the antioxidant thioctic acid (alpha-lipoic acid): a two year multicenter randomized double-blind placebo-controlled trial (ALADIN II). Alpha Lipoic Acid in Diabetic Neuropathy. M. Reljanovic, G. Reichel, K. Rett, M. Lobisch, K. Schuette, W. Moller, H. J. Tritschler, H. Mehnert. Free Radic Res 1999: 171–9 10499773
Alpha-lipoic acid improves peripheral insulin sensitivity in patients with type 2 diabetes. P. Kamenova, D. Koev, L. Dakovska, G. Kirilov, A. Nicheva. Endocrinologia 2002: 19–24
A multicentre, open-label, follow-on study to assess the long-term maintenance of effect, tolerance and safety of THC/CBD oromucosal spray in the management of neuropathic pain. B. Hoggart, S. Ratcliffe, E. Ehler, K. H. Simpson, J. Hovorka, J. Lejčko, L. Taylor, H. Lauder, M. Serpell. J Neurol 2015: 27–40 25270679
Predictors of improvement and progression of diabetic polyneuropathy following treatment with alpha-lipoic acid for 4 years in the NATHAN 1 trial. D. Ziegler, P. A. Low, R. Freeman, H. Tritschler, A. I. Vinik. J Diabetes Complications 2016: 350–6 26651260

### Other reason

Electroacupuncture to treat painful diabetic neuropathy: study protocol for a three-armed, randomized, controlled pilot trial. S. Lee, J. H. Kim, K. M. Shin, J. E. Kim, T. H. Kim, K. W. Kang, M. Lee, S. Y. Jung, M. S. Shin, A. R. Kim, H. J. Park, K. E. Hong, S. M. Choi. Trials 2013: 225 23866906
Effect of aerobic exercise on quality of life in population with diabetic peripheral neuropathy in type 2 diabetes: a single blind, randomized controlled trial. S. Dixit, A. Maiya, B. Shastry. Qual Life Res 2014: 1629–40 24326731
Fifteen-day acupuncture treatment relieves diabetic peripheral neuropathy. Y. Tong, H. Guo, B. Han. J Acupunct Meridian Stud 2010: 95–103 20633522
Clinical effects of acupuncture for diabetic peripheral neuropathy. C. Zhang, Y. X. Ma, Y. Yan. J Tradit Chin Med 2010: 13–4 20397454
Effective treatment of symptomatic diabetic polyneuropathy by high-frequency external muscle stimulation. L. Reichstein, S. Labrenz, D. Ziegler, S. Martin. Diabetologia 2005: 824–8 15830180
Electrical spinal-cord stimulation for painful diabetic peripheral neuropathy. S. Tesfaye, J. Watt, S. J. Benbow, K. A. Pang, J. Miles, I. A. MacFarlane. Lancet 1996: 1698–701
Effect of treatment with capsaicin on daily activities of patients with painful diabetic neuropathy. Capsaicin Study Group.. Diabetes Care 1992: 159–65 1547671
Clinical study on the wrist-ankle acupuncture treatment for 30 cases of diabetic peripheral neuritis. H. Jiang, K. Shi, X. Li, W. Zhou, Y. Cao. J Tradit Chin Med 2006: 8–12 16705843
Nerve conduction studies after decompression in painful diabetic polyneuropathy. J. F. Macare van Maurik, H. Franssen, D. W. Millin, E. J. Peters, M. Kon. J Clin Neurophysiol 2015: 247–50 26035677
Randomized, placebo-controlled comparison of amitriptyline, duloxetine, and pregabalin in patients with chronic diabetic peripheral neuropathic pain: impact on pain, polysomnographic sleep, daytime functioning, and quality of life. J. Boyle, M. E. Eriksson, L. Gribble, R. Gouni, S. Johnsen, D. V. Coppini, D. Kerr. Diabetes Care 2012: 2451–8 22991449
A multicentre, open-label, follow-on study to assess the long-term maintenance of effect, tolerance and safety of THC/CBD oromucosal spray in the management of neuropathic pain. B. Hoggart, S. Ratcliffe, E. Ehler, K. H. Simpson, J. Hovorka, J. Lejčko, L. Taylor, H. Lauder, M. Serpell. J Neurol 2015: 27–40 25270679
Efficacy and safety of 40 mg or 60 mg duloxetine in Japanese adults with diabetic neuropathic pain: Results from a randomized, 52-week, open-label study. H. Yasuda, N. Hotta, M. Kasuga, A. Kashiwagi, R. Kawamori, T. Yamada, Y. Baba, L. Alev, K. Nakajo. Journal of Diabetes Investigation 2015: #Pages#
Efficacy and safety of methylcobalamin, alpha lipoic acid and pregabalin combination versus pregabalin monotherapy in improving pain and nerve conduction velocity in type 2 diabetes associated impaired peripheral neuropathic condition. [MAINTAIN]: Results of a pilot study. D. Vasudevan, M. M. Naik, Q. I. Mukaddam. Ann Indian Acad Neurol 2014: 19–24 24753654
Comparative safety and tolerability of duloxetine vs. pregabalin vs. duloxetine plus gabapentin in patients with diabetic peripheral neuropathic pain. G. Irving, R. J. Tanenberg, J. Raskin, R. C. Risser, S. Malcolm. Int J Clin Pract 2014: 1130–1140 24837444
Treatment of symptomatic diabetic polyneuropathy with the antioxidant alpha-lipoic acid: a 7-month multicenter randomized controlled trial (ALADIN III Study). ALADIN III Study Group. Alpha-Lipoic Acid in Diabetic Neuropathy. D. Ziegler, M. Hanefeld, K. J. Ruhnau, H. Hasche, M. Lobisch, K. Schutte, G. Kerum, R. Malessa. Diabetes Care 1999: 1296–301 10480774
Treatment of symptomatic diabetic peripheral neuropathy with the anti-oxidant alpha-lipoic acid. A 3-week multicentre randomized controlled trial (ALADIN Study). D. Ziegler, M. Hanefeld, K. J. Ruhnau, H. P. Meissner, M. Lobisch, K. Schutte, F. A. Gries. Diabetologia 1995: 1425–33 8786016
Supplementation of A-Lipoic acid in diabetic peripheral neuropathy: A prospective open label randomized controlled trial. P. R. Anand Vijayakumar, S. M. Kalshetti, J. K. Bhatt. International Journal of Pharmacy and Pharmaceutical Sciences 2014: 90–93
Pregabalin for relief of neuropathic pain associated with diabetic neuropathy: A randomized, double-blind study. T. Tölle, R. Freynhagen, M. Versavel, U. Trostmann, J. P. Young Jr. European Journal of Pain 2008: 203–213 17631400
Duloxetine in the long-term management of diabetic peripheral neuropathic pain: An open-label, 52-week extension of a randomized controlled clinical trial. J. F. Wernicke, J. Raskin, A. Rosen, Y. L. Pritchett, D. N. D’Souza, S. Iyengar, K. Knopp, T. K. Le. Current Therapeutic Research - Clinical and Experimental 2006: 283–304
Treatment with alpha-lipoic acid over 16 weeks in type 2 diabetic patients with symptomatic polyneuropathy who responded to initial 4-week high-dose loading. H. Garcia Alcala, C. I. Santos Vichido, S. Islas Macedo, C. N. Genestier Tamborero, M. Minutti Palacios, O. Hirales Tamez, C. Garcia, D. Ziegler. J Diabetes Res 2015: #Pages#
Impact of low frequency pulsed magnetic fields on pain intensity, quality of life and sleep disturbances in patients with painful diabetic polyneuropathy. M. P. Wrobel, A. Szymborska-Kajanek, G. Wystrychowski, T. Biniszkiewicz, K. Sieron-Stoltny, A. Sieron, K. Pierzchala, W. Grzeszczak, K. Strojek. Diabetes Metab 2008: 349–54 18585071
Safety and effectiveness of topiramate for the management of painful diabetic peripheral neuropathy in an open-label extension study. P. D. Donofrio, P. Raskin, N. R. Rosenthal, D. J. Hewitt, D. M. Jordan, J. Xiang, A. I. Vinik. Clin Ther 2005: 1420–31 16291415
Efficacy and safety of 40 mg or 60 mg duloxetine in Japanese adults with diabetic neuropathic pain: Results from a randomized, 52-week, open-label study. H. Yasuda, N. Hotta, M. Kasuga, A. Kashiwagi, R. Kawamori, T. Yamada, Y. Baba, L. Alev, K. Nakajo. J Diabetes Investig 2016: 100–8
Quality of life increases in patients with painful diabetic neuropathy following treatment with spinal cord stimulation. R. V. Duarte, L. Andronis, M. W. Lenders, C. C. de Vos. Qual Life Res 2015: #Pages#
A randomized double-blind, placebo-, and active-controlled study of T-type calcium channel blocker ABT-639 in patients with diabetic peripheral neuropathic pain. D. Ziegler, W. Rachel Duan, G. An, J. W. Thomas, W. Nothaft. Pain 2015: 2013–2020 26067585
Amitriptyline 2% cream vs. Capsaicin 0.75% cream in the treatment of painful diabetic neuropathy (double blind, randomized clinical trial of efficacy and safety). J. Kiani, S. A. Nasrollahi, F. Esna-Ashari, P. Fallah, F. Sajedi. Iranian Journal of Pharmaceutical Research 2015: 1263–1268 26664395
A multicentre, open-label, follow-on study to assess the long-term maintenance of effect, tolerance and safety of THC/CBD oromucosal spray in the management of neuropathic pain. B. Hoggart, S. Ratcliffe, E. Ehler, K. H. Simpson, J. Hovorka, J. Lejčko, L. Taylor, H. Lauder, M. Serpell. J Neurol 2015: 27–40 25270679
Sustained treatment effect of spinal cord stimulation in painful diabetic peripheral Neuropathy: 24-Month Follow-up of a prospective Two-Center randomized controlled trial. M. Van Beek, R. Slangen, N. C. Schaper, C. G. Faber, E. A. Joosten, C. D. Dirksen, R. T. Van Dongen, A. G. H. Kessels, M. Van Kleef. Diabetes Care 2015: e132–e134 26116722
Treatment with alpha-lipoic acid over 16 weeks in type 2 diabetic patients with symptomatic polyneuropathy who responded to initial 4-week high-dose loading. H. Garcia-Alcala, C. I. Santos Vichido, S. Islas Macedo, C. N. Genestier-Tamborero, M. Minutti-Palacios, O. Hirales Tamez, C. Garcia, D. Ziegler. J Diabetes Res 2015: #Pages#
Clinical Trial Assessing the Efficacy of Gabapentin Plus B Complex (B1/B12) versus Pregabalin for Treating Painful Diabetic Neuropathy. A. Mimenza Alvarado, S. Aguilar Navarro. J Diabetes Res 2016: 4078695 26885528
Efficacy of Inhaled Cannabis on Painful Diabetic Neuropathy. M. S. Wallace, T. D. Marcotte, A. Umlauf, B. Gouaux, J. H. Atkinson. J Pain 2015: 616–27 25843054
Two styles of acupuncture for treating painful diabetic neuropathy--a pilot randomised control trial. A. C. Ahn, T. Bennani, R. Freeman, O. Hamdy, T. J. Kaptchuk. Acupunct Med 2007: 11–7 17641562