# Appendix B Detailed Search Strategy

## PubMed

A (diabetes neuropathy) | B (Interventions for KQ1 and 2)
diabetes mellitus[mh] OR diabetes [tiab] AND peripheral nervous system diseases [mh] OR “Peripheral Nerve Diseases”[tiab] OR “Peripheral Nerve Diseases”[tiab] OR neuropathy[tiab] OR Polyneuropathy[tiab] OR “Peripheral Nerve Disease”[tiab] OR neuropathies[tiab] OR Polyneuropathies[tiab] OR “PNS disease”[tiab] OR “PNS diseases”[tiab] OR “Diabetic Neuropathies” [MH] OR neuropathy[tiab] OR “diabetic polyneuropathy” [tiab] | “hypoglycemic agents”[mh] OR Hypoglycemic[tiab] OR hypoglycaemic [tiab] OR antidiabetic[tiab] OR Antihyperglycemic[tiab] OR “insulin infusion systems”[MeSH Terms] OR insulin [tiab] OR “glycemic control”[tiab] OR “glycaemic control”[tiab] OR “metformin”[mh] or “thiazolidinediones”[mh] or “glipizide”[mh] or “glyburide”[mh] OR “Dipeptidyl-Peptidase IV Inhibitors”[mh] OR “Glucagon-Like Peptide 1”[mh] OR biguanide*[tiab] OR metformin[tiab] OR thiazolidinedione*[tiab] or pioglitazone[tiab] OR rosiglitazone[tiab] OR sulfonylurea*[tiab] or sulphonylurea*[tiab] OR glipizide[tiab] OR glyburide[tiab] OR glimepiride[tiab] OR glibenclamide[tiab] OR “insulin secretagogues”[tiab] OR sitagliptin*[tiab] OR saxagliptin*[tiab] OR dpp- 4[tiab] OR(exercise [mh]) OR ((exercise[tiab] or exercises[tiab]) AND (program[tiab] OR programs[tiab] OR intervention [tiab] OR interventions [tiab] OR balance [tiab] OR coordination[tiab] OR coordinations[tiab] OR aerobic[tiab] OR isometric[tiab] OR therapy OR strength[tiab] OR endurance[tiab] OR endurances[tiab] OR running[tiab] OR walking [tiab] OR cycle[tiab] OR treadmill[tiab] OR stair[tiab]))) OR physical exertion[mh] OR ((physical [tiab]) AND (activity[tiab] OR activities[tiab] OR fitness [tiab] OR therapy[tiab] OR exercise[tiab] OR education[tiab] OR training[tiab] OR exertion[tiab] OR exertions[tiab] OR effort[tiab] OR efforts[tiab]))) OR Rehabilitation[mh] OR Rehabilitation[tiab] OR (training [tiab] AND (aerobic [tiab] OR resistance[tiab] OR strength [tiab] OR balance [tiab] OR endurance[tiab] OR endurances[tiab] OR weight[tiab])) Sports[mh] OR ((therapy[tiab] OR therapies[tiab]) AND (moving[tiab] OR sports[tiab]))) OR “Stair Navigation”[tiab] OR postural balance[mh] OR “postural stability”[tiab] OR posture[mh] or posture[tiab] OR postures[tiab] or “postural control” [tiab] OR muscle strength[mh] OR muscle strength[tiab] OR proprioception[mh] OR Proprioception[tiab] OR)) OR Weight-Bearing[mh] OR WeightBearing[tiab] OR “weight loss”[mh] OR “weight loss”[tiab] OR “Diet, Carbohydrate-Restricted”[mh] OR diet[tiab] OR “smoking cessation”[mh] OR “smoking cessation”[tiab] OR “lifestyle intervention”[tiab] OR “physical therapy”[tiab] OR” Physical Therapy Modalities”[mh] OR Rehabilitation[mh] OR Rehabilitation[tiab] OR (Acupuncture [MH])) OR ((acupuncture[tiab]) AND (injection[tiab] OR therapy [tiab] points[tiab] OR therapy[tiab]))) OR (“decompression, surgical”[mh] OR “surgical decompression”[tiab])) OR “electric stimulation therapy”[mh]) OR (((neural [tiab] OR nerve[tiab] OR therapy[tiab])) AND stimulation[tiab])) OR “TENS”[tiab]) OR (Cognitive therapy [mh] OR “Cognitive therapy” [tiab] OR “Cognitive behavioral”[tiab] or “cognition therapy”[tiab] OR “cognitive Psychotherapy”[tiab] OR “behavioral therapy”[tiab] OR “behavioral therapies”[tiab] OR “thioctic acid”[mh] OR “lipoid acid”[tiab] OR “thioctic acid”[tiab] OR acetylcarnitine[mh] OR Acetylcarnitine [tiab] OR “Acetyl-L-Carnitine”[tiab] OR carnitine[tiab])) OR ((((((((((diabetes mellitus[mh] OR diabetes [tiab])) AND (peripheral nervous system diseases [mh] OR “Peripheral Nerve Diseases”[tiab] OR “Peripheral Nerve Diseases”[tiab] OR neuropathy[tiab] OR Polyneuropathy[tiab] OR “Peripheral Nerve Disease”[tiab] OR neuropathies[tiab] OR Polyneuropathies[tiab] OR “PNS disease”[tiab] OR “PNS diseases”[tiab]))) OR (“Diabetic Neuropathies” [MH] OR neuropathy[tiab] OR “diabetic polyneuropathy” [tiab]))) AND (((“Neuralgia”[Mesh] OR neuralgia [tiab]OR “Neuropathic pain”[tiab] OR “Trigeminal neuralgia”[tiab])) AND (“therapy”[Subheading] OR “therapy”[tiab] OR “treatment”[tiab] OR “Therapeutic Uses”[mh] OR “therapeutics”[MeSH Terms] OR “therapeutics”[tiab]))))