# Appendix A List of Acronyms

%: percent
ABC: Activities-specific Balance and Confidence scale
ACROBAT-NRSI: Cochrane Risk of Bias Assessment Tool for Non-Randomized Studies of Interventions
AHRQ: Agency for Healthcare Research and Quality
ALA: Alpha-lipoic Acid
ALADIN: Alpha-Lipoic Acid in Diabetic Neuropathy Trial
ATL: Achilels tendon lengthening
BBS: Berg Balance Scale
BMI: Body Mass Index
BMT: Best Medical Treatment
CBT: Cognitive Behavioral Therapy
CDC: Centers for Disease Control
CI: Confidence interval
DCCT: Diabetic Control and Complications Trial
DPN: Diabetic Peripheral Neuropathy
EDIC: Epidemiology of Diabetes Interventions and Complications
EPC: Evidence-based practice center
FDA: Food and Drug Administration
FES: Falls Efficacy Scale
FES-I: Falls Efficacy Scale – Internation version
FRT: Functional Reach Test
HbA1c: Glycated Haemoglobin
HR: Hazard Ratio
IWGDF: International Working Group on the Diabetic Foot
J-EDIT: Japanese Elderly Diabetes Intervention Trial
KQ: Key Question
LAC: Levacecarnine
MDM: Mesodiencephalic moedulation
MPQ-QOL: McGill Pain Questionnaire – Quality of Life
NEURODIAB: Diabetic Neuropathy Study Group of the European Association for the Study of Diabetes
NMDA: N-methyl-D-aspartate
NPSI: Neuropathic Pain Symptom Inventory
NQOL: Neuropathic Quality of Life
NR: Not reported
NS: Not significant
NSC(LL): Neuropathy Symptom Change Score – Lower Legs
OR: odds ratio
ORPIL: Oral Pilot Trial
PEMF: Pulsed electromagnetic fields
PENS: Percutaneous Electrical Nerve Stimulation
PICOTS: Populations, interventions, comparators, outcomes, timing, setting
QOL: Quality of Life
RCT: Randomized controlled trial
RR: Relative risk
rTMS: repetitive transcranial magnetic stimulation
SCS: Spinal Cord Stimulation
SD: Standard deviation
SDIS: Stockholm Diabetes Intervention Study
SF-36: 36 item Short Form Survey
SMD: Standardized Mean Difference
SNRI: Serotonin-Norepinephrine Reuptake Inhibitors
SOE: Strenght of Evidence
SYDNEY2: Sumptomatic Diabetic Neuropathy Trial
T2DM: Type 2 diabetes mellitus
TCA: Tricyclic antidepressants
TCC: Total Contact Casting
TENS: Transcutaneous Electrical Nerve Stimulation
TOO: Task Order Officer
TUG: Timed Up and Go Test
VACSDM: Veterans Affairs Cooperative Study on Glycemic Control and Complications in Type II Diabetes
VAS: Pain Visual Analogue Scale
WHYMPI: West Haven Yale Multidimensional Pain Inventory