# Results

## Results of Literature Searches for Key Questions

We identified 6573 nonduplicative titles or abstracts with potential relevance, with 485 proceeding to full text review (Figure 2). We excluded 468 studies at full text review. We included 17 unique studies (17 publications; one publication reports two separate studies^18^ and one study was reported in two papers^19, 20^) in the review. These 17 studies included 13 randomized controlled trials (RCTs), one nonrandomized trial, and three retrospective cohort studies. In addition to these 17 studies published since the completion of our original review of therapies for children with autism spectrum disorder (ASD) in 2011,^14^ we include seven comparative studies addressed in the 2011 review in order to present a comprehensive assessment of the literature addressing interventions targeting sensory challenges.

Figure 2 Disposition of studies identified for this review

Numbers next to each Key Question indicate number of unique studies addressing the question. Studies could address more than one Key Question.

^*^ Numbers do not tally as studies could be excluded for multiple reasons.

^†^ One paper reports two separate trials. We also include analysis of 7 comparative studies reported in our 2011 review of therapies for children with ASD; thus, we describe a total of 24 studies.

Abbreviations: KQ = Key Question; n = number.

Figure 2 outlines the disposition of studies identified for this review. We identified 6573 nonduplicative titles or abstracts with potential relevance, with 485 proceeding to full text review. We excluded 468 studies at full text review. We included 17 unique studies publications in the review. We also include summaries of 7 comparative studies of sensory approaches addressed in our earlier review of therapies for children with ASD (Warren et al. 2011); thus, we describe 24 unique studies in the review.

### Description of Included Studies

The 24 studies addressing interventions targeting sensory challenges included 20 RCTs (including one paper that reported two separate studies^18–37^ one nonrandomized trial, ^38^ and three retrospective cohort studies^39–41^ (Table 2). Three studies had low risk of bias,^22, 24, 37^ 10 had moderate,^19–21, 23, 25, 27, 28, 33–36^ and 11 had high risk.^18, 26, 29–32, 38–41^ Fourteen studies were conducted in the United States,^18–26, 29, 33, 34, 36, 40^ two in the UK,^28, 35^ two in Korea,^30, 41^ and one each in Japan,^39^ Iran,^38^ Turkey,^31^ Brazil,^37^ Thailand,^32^ and Australia.^27^

Table 2 Overview of studies addressing interventions targeting sensory challenges

Characteristic | RCTs (n=20) | Nonrandomized Trials (n=1) | Retrospective Cohort Studies (n=3) | Total Literature
Intervention Category
Sensory integration-based approaches | 3 | 0 | 1 | 4
Environmental enrichment-based approaches | 2 | 0 | 0 | 2
Auditory integration-based approaches | 4 | 0 | 0 | 4
Music therapy-based approaches | 4 | 1 | 0 | 5
Massage-based approaches | 5 | 0 | 2 | 7
Additional approaches | 2 | 0 | 0 | 2
Treatment Duration
<1–4 weeks | 5 | 1 | 0 | 6
5–8 weeks | 2 | 0 | 0 | 2
9–12 weeks | 4 | 0 | 0 | 4
13–20 weeks | 6 | 0 | 2 | 8
≥21 weeks | 3 | 0 | 1 | 4
Region of Study Conduct
Asia | 3 | 1 | 2 | 6
Australia | 1 | 0 | 0 | 1
Europe | 2 | 0 | 0 | 2
North America | 13 | 0 | 1 | 14
South America | 1 | 0 | 0 | 1
Risk of Bias
Low | 3 | 0 | 0 | 3
Moderate | 10 | 0 | 0 | 10
High | 7 | 1 | 3 | 11
Total N Participants | 790 | 27 | 193 | 1010

N = Number; RCT = Randomized Controlled Trial

In total, studies included approximately 1010 children (median 34 total children/study) ranging in age from 2 to 16 years. Overlap of participants in a series of massage-focused studies by one investigative team is unclear. While studies likely included some of the same children, the extent of overlap is not clear.^25, 26, 33, 36, 40^

Severity of ASD and sensory dysfunction varied across studies. Only two studies reported any followup of participants after the completion of treatment,^26, 38^ and one had more than 6 months of treatment^39^ while another planned for 5 months of treatment but required 7 months to complete the intervention.^37^ Because few studies addressed sub-questions under Key Questions (KQ) 1 and 2, we present results in the aggregate under each of these KQ. Appendix G includes detailed summary tables summarizing key outcomes.

Table 3 outlines outcome areas targeted in studies meeting our review criteria. Most studies addressed sensory challenges and symptom severity.

Table 3 Overview of key outcome areas targeted

Intervention/Outcomes Targeted | ASD Symptom Severity | Sensory Challenges | Language/Communication | Social Engagement | Nonverbal Cognitive Skills | Challenging Behaviors | Adaptive Behavior | Sleep | Harms of Intervention
Sensory Integration-based Approaches^21, 22, 31, 39^ | X | X | | X | X | | X
Environmental enrichment-based Approaches^23, 24^ | X | | X | | X
Auditory Integration-based Approaches^18, 34, 35^ | X | X | X | | | X
Music Therapy^19, 20, 27, 30, 37, 38^ | X | X | X | X
Massage-based Approaches^25, 26, 32, 33, 36, 40, 41^ | X | X | | X | | X | X | X
Tactile-based Task^29^ | | | X | | X
Weighted Blanket^28^ | X | X | | | | | | X | X

ASD= autism spectrum disorder

Note: X=Outcome area addressed by a study in the intervention category noted

### Gray Literature

Our searches of ClinicalTrials.gov and other trial registries did not yield additional eligible studies for the review. We used information from organization Web sites searched to provide additional context for the discussion section of the report.

## Key Question 1 Benefits and Harms of Interventions Targeting Sensory Challenges

### Studies of Sensory Integration-Based Approaches

#### Key Points

- Four studies addressing sensory integration (SI)-based approaches were small and short-term (typically <6 months), with no followup beyond the immediate treatment period. No study reported harms of intervention.
- Sensory-related outcomes improved in children receiving an SI-based intervention compared with those receiving usual care or other treatment (statistically significant improvements in three of four studies addressing the outcome). We have low confidence in this conclusion (low strength of evidence).
- Motor skills outcomes were improved in children receiving SI-based treatment compared with those receiving usual care or other treatment (statistically significant improvements in three of three studies addressing the outcome). We have low confidence in this conclusion (low strength of evidence).
- We could not assess the effects of SI-based treatment on adaptive behavior given differences in outcomes measures (insufficient strength of evidence).

#### Overview of the Literature

We identified three RCTs (one low,^22^ one moderate,^21^ and one high^31^ risk of bias) and one retrospective cohort study (high risk of bias^39^) addressing SI-based approaches. These studies included one RCT with high risk of bias addressed in our 2011 review.^31^ All four studies included either explicitly noted that they were based on Ayres sensory integration principles^21, 22^ or noted using a coordinated program of specific sensory-based activities selected based on a given child’s needs and incorporated into the child’s daily routine.^31, 39^ Studies were conducted in the United States,^21, 22^ Japan,^39^ and Turkey^31^ and included a total of 119 children between the ages of 2 to 12 years. Treatment duration ranged from 6 weeks to 10 months, and no study reported long-term followup after the end of treatment.

#### Detailed Analysis

In these small, short-term studies, outcomes on sensory-related measures and motor skills measures were improved in children receiving a SI-based intervention compared with another intervention in three of four studies, but effects on other outcomes were typically not statistically significantly different between groups (Appendix G). Several outcomes were also parent-reported, and parents were often aware of intervention status.

In one low risk of bias RCT, children with autism or Pervasive Development Disorder-Not Otherwise Specified (PDD-NOS) and a diagnosed sensory processing disorder received SI-based treatment or treatment focused on building fine motor skills.^22^ Intervention for both groups consisted of 18 45-minute sessions over a 6-week span. Both groups improved significantly on blinded parent and teacher ratings of goal attainment (Goal Attainment Scale [GAS]) related to sensory processing, motor skills, and social functioning, with children receiving SI improving significantly more than those receiving motor skills intervention (p values ≤0.05). Children in the SI group had significantly fewer parent-rated autistic mannerisms post-treatment than the fine motor group (p≤0.05), but other measures of sensory processing, ASD symptoms, or neurological functioning did not differ between groups.

Another RCT with moderate risk of bias compared manualized occupational therapy with sensory integration (OT/SI) to care-as-usual.^21^ OT/SI treatment consisted of three weekly sessions over the course of 10 weeks, which were monitored for treatment fidelity. Outcome measurements included parent-generated GAS. After treatment, children receiving OT/SI showed significantly more goals attained and significantly greater improvements in social skills and self-care measures compared with children receiving usual care (p=0.003). Scores on the Vineland Adaptive Behavior Scales (VABS) or other measures related to functional skills did not differ between groups. Children receiving OT/SI had greater improvements in need for caregiver assistance with self-care and social skills (p values ≤0.05).

In a retrospective cohort study (high risk of bias) using previously collected data to compare SI-based therapy in children with high functioning ASD (IQs > 70), both groups received active treatment that included either SI therapy or eclectic group therapy.^39^ Treatment lasted for 8 to 10 months. Participants in the SI group improved significantly more than those in the control group in measures of motor abilities, memory and visualization, and combined sensory motor and cognitive skills conducted by an unblinded investigator (p values<0.05) but not for measures of spatial positioning and sense of touch or verbal ability. Finally, in a high risk of bias RCT evaluating the effects of an SI protocol on low-functioning children with ASD, children receiving SI intervention had significantly fewer sensory problems at followup than children in the usual care control group using a parent-rated scale.^31^

### Studies of Environmental Enrichment-Based Approaches

#### Key Points

- Two small RCTs addressing environmental enrichment were short term (<6 months). Neither study reported harms of intervention.
- Environmental enrichment approaches improved nonverbal cognitive skills. We have low confidence in this conclusion (low strength of evidence).
- These approaches do not affect expressive language. We have low confidence in this conclusion (low strength of evidence)
- We could not make conclusions about effects on atypical sensory responses or receptive language as these outcomes were only addressed in one RCT (insufficient strength of evidence).

#### Overview of the Literature

Two RCTs (low and moderate risk of bias), both conducted by the same investigators in the United States, examined environmental enrichment.^23, 24^ The 78 children included in studies range in age from 3 to 12 years and received treatment for 6 months, with followup immediately post-treatment in both studies. Children in the studies had specific diagnoses of autism (vs. ASD).

#### Detailed Analysis

Two small RCTs of environmental enrichment examined the same protocol and reported improvements in ASD symptoms, receptive language, and nonverbal cognitive skills after 6 months of treatment (Appendix G). In one RCT (moderate risk of bias) comparing male children who received standard care plus sensorimotor enrichment to those who received standard care alone, the treatment group received olfactory/tactile stimulation as well as four to seven other parent-led, sensory-stimulating exercises twice a day over the course of 6 months.^23^ Levels of concurrent interventions (e.g., speech, behavioral, physical therapies) were similar across groups and held as stable as possible. Compared with usual care, children receiving environmental enrichment had a more significant decrease in clinician-rated ASD symptoms (p=0.03) at the end of treatment, with nearly five times as many participants in the treatment group showing clinically significant drops of five points or more (42% vs. 7%, p=0.03). The treatment group also had a 9-point increase in nonverbal cognitive skills as measured by the Leiter-R compared with a decrease of approximately 3 points in the usual care group (p=0.008). Both groups improved on expressive language skills, with no significant differences.

A second RCT (low risk of bias) built upon the preliminary work by examining use of the same sensorimotor enrichment regimen over 6 months.^24^ Investigators randomized participants to three groups: full treatment, as described in the initial study above; partial treatment, which entailed an abbreviated treatment regimen, and standard care. However, because no differences were found between intervention outcomes across the two treatment groups, the study collapsed findings into a combined treatment group. The treatment groups experienced significant attrition (> 50% across both) that may affect the generalizability of the results. After 6 months, the treatment group showed more improvement than did the control group in receptive language skills, but both groups improved comparably for expressive language. The treatment group had significantly more improvement on mean nonverbal IQ scores as well as parent-rated sensory reactivity. Although more children in the treatment group compared with the control group shifted their diagnostic classification on the Autism Diagnostic Observation Schedule-2 (ADOS-2) from “autism” to “autism spectrum,” all children across both groups continued to meet the cut-offs for ASD, making it difficult to interpret the clinical significance of the findings.

### Studies of Auditory Integration-Based Approaches

#### Key Points

- All four RCTs addressing auditory integration-based approaches were small and short term (<6 months). No study reported harms of intervention.
- Auditory integration-based approaches do not improve language outcomes. We have low confidence in this conclusion (low strength of evidence).

#### Overview of the Literature

Four RCTs with moderate^34, 35^ and high^18^ risk of bias evaluated auditory integration-based approaches. One paper reports two RCTs,^18^ and two studies were included in our 2011 review.^34, 35^ Studies included a total of 173 children between the ages of 3 and 13 years, and treatment duration ranged from 1 week to 18 weeks, with followup immediately post-treatment.

#### Detailed Analysis

Two small, short term RCTs of auditory integration-based approaches reported no significant differences between groups in language outcomes assessed on parent, teacher, and clinician observation measures,^34, 35^ while two studies reported significant parent-rated improvements in hearing sensitivity and behavior (Appendix G).^18^

One crossover RCT evaluated the effects of Tomatis Sound Therapy on language skills in children with autistic disorder who had not previously had auditory stimulation treatments.^34^ In the treatment condition, children listened to music passed through an electronic ear for attenuation and modulation for two hours per day in accordance with the Tomatis Method protocol. In the placebo condition, children listened to commercially produced music. The study reported no significant group effects. Another RCT of auditory integration therapy including children with significant language delays reported no significant benefits of auditory integration.^35^

Two high risk of bias RCTs (reported in a single publication^18^) examined the use of auditory integration strategies theorized to reduce auditory hypersensitivity by “exercising” the neural regulation abilities of the middle ear muscles. Across both trials, two different sets of participants completed five 45-minute sessions on consecutive days. In Trial 1, participants wore headphones and either listened to filtered music or no sound. In Trial 2, participants either listened to filtered music or unfiltered music. Participants either had at least five words of functional speech or were able to follow one-step instructions. It should be noted that although the ADI-R was used to confirm diagnosis, a subset of participants did not meet full diagnostic cut-offs on this instrument. One week after intervention, parents reported more improvement in the areas of hearing sensitivity, spontaneous speech, listening, and behavioral organization after filtered music compared with children in the control condition (p values <0.01). Children who received filtered music in Trial 2 also had significantly better parent-rated scores on hearing sensitivity and emotional control compared with control children (p values <0.05). Groups in either trial did not differ in the other behavioral domains rated.

### Studies of Music Therapy-Based Approaches

#### Key Points

- All studies addressing music therapy-based approaches were small and short term (<6 months), and none reported harms of intervention.
- We could not make conclusions about effects of music therapy approaches on any outcome given that studies had multiple comparators and addressed different outcomes (insufficient strength of evidence).

#### Overview of the Literature

Four RCTs and one nonrandomized trial (one conducted in Australia,^27^ one in Iran,^38^ one in Brazil,^37^ one in the United States, ^19, 20^ and one in Korea^30^) examined music therapy-based approaches. One study compared a rhythm-based intervention with a non-human (robot) control and with human-delivered control intervention.^19, 20^ One nonrandomized trial comparing music therapy and toy play was included in our 2011 review.^30^

Studies included a total of 115 children ranging in age from 3 to 12 years, and treatment duration ranged from 45 days to 20 weeks. Followup occurred immediately at the end of treatment in all but one of the studies, which followed up at 2 months post-treatment.^38^ Two studies had low risk of bias,^19, 20, 37^ one had moderate risk of bias,^27^ and two studies had high risk.^30, 38^

#### Detailed Analysis

The five small studies addressing music therapy reported some significant effects on measures of behavior (social engagement, behavioral organization), verbal and nonverbal communication, and joint attention (directing and sharing attention to objects or events) with music-based intervention compared with control interventions (Appendix G). Studies used different protocols and addressed different outcomes; thus, drawing conclusions across studies is challenging. In some studies children also received other interventions in addition to music-based approaches.

One RCT (low risk of bias) compared Relational Music Therapy to treatment-as-usual in 24 male children with Autistic disorder, PDD-NOS, or Asperger Syndrome.^37^ Relational Music Therapy is not a standardized protocol but rather a participant-driven, non-directive approach that incorporates musical instruments to promote interaction. Intervention consisted of 16 30-minute sessions that took approximately 7 months to complete. Groups did not differ significantly on outcomes measured using the Childhood Autism Rating Scale (CARS) at followup.

Another low risk of bias RCT compared three intervention conditions (four 45-minute sessions/week for 8 weeks) targeting pre- and post-test measures of communication, attention, and motor skills: a trainer-led rhythm and movement-based group, a robot group focused on imitation, and a control group engaging in tabletop activities.^19, 20^ The rhythm and control groups improved from baseline on an overall measure of joint attention, while the robot group did not; between-group differences were not statistically significant. Both rhythm and robot treatment groups demonstrated greater post-test attention to trainers than to objects than did the control group (p values <0.001), with greater attention in the rhythm group than the robot group (p<0.001). The rhythm group also demonstrated the greatest duration of spontaneous social attention, followed by the robot group and the control group (p<0.001). Children in the robot group also had greater self-directed vocalization compared with the other groups (p values <0.002), while children in the rhythm and control groups had greater spontaneous social verbalization to trainers than did children in the robot group (p values <0.03).

One RCT (moderate risk of bias) compared family-centered music therapy plus early intervention to early intervention only.^27^ Participants had little to no functional verbal communication and received 2 to 3 hours of community-based intervention per week while participating. Intervention consisted of one hour per week of semi-structured sessions within the home for 16 weeks. Therapists worked with parents and participants to improve selected core social engagement skills through music-based activities. Children who received music therapy had more improvement than controls in parent-rated social engagement (p< 0.001) but remained significantly impaired relative to typically developing peers. Groups did not differ on parent-reported autism symptoms, speech and language, or quality of the parent-child relationship.

In a high risk of bias nonrandomized trial comparing 12 1-hour Orff-Schulwerk music therapy sessions over the course of 45 days to no treatment, social skills improved significantly in the treatment group between baseline to post-treatment but not from post-treatment to follow-up.^38^ The control group did not improve at any time point, and differences between the treatment and control groups were not significant at the final followup.

In a final crossover RCT with high risk of bias comparing music therapy and toy play, groups did not differ on the Pervasive Development Disorder Behavior Inventory (PDDBI), though both groups improved with time.^30^ Results from the Early Social Communication Scales, reflecting growth in joint attention skills, suggested that music therapy was significantly more effective than play sessions. Change scores pre- to post-music therapy were significantly greater than change scores pre- to post-play sessions. In coding for emotional and motivational responsiveness (i.e., joy, emotional synchronicity, initiation of engagement), investigators observed more joy, emotional synchronicity, and initiation of engagement during music therapy than in play sessions. In addition, children had significantly more compliant behavior and significantly fewer episodes of no response behaviors in the music therapy condition.

### Studies of Touch/Massage

#### Key Points

- One group of investigators conducted five short-term (<6 months treatment duration) studies comparing massage with no massage treatment, and participant overlap is unclear. No study reported harms of intervention.
- Additional studies assessed massage therapy plus attachment therapy compared with attachment therapy alone or massage plus SI-based treatment vs. SI-based treatment alone.
- Massage improved sensory challenges and ASD symptom severity vs. no massage. Our confidence in this conclusion is low (low strength of evidence).
- Massage did not improve maladaptive behavior. Our confidence in this conclusion is low (low strength of evidence).
- We could not make conclusions about the effects of massage on language/communication outcomes given inconsistent findings and use of different outcome measures (insufficient strength of evidence).
- We could not make conclusions about longer-term outcomes (≥6 months) as only one study reported longer-term followup (insufficient strength of evidence). We could not make conclusions about effects on measures of daily living skills, also assessed in only one study (insufficient strength of evidence). Only one study compared massage plus SI-based treatment to SI-based treatment alone or attachment therapy plus massage with attachment therapy alone so we could not make conclusions about these studies (insufficient strength of evidence).

#### Overview of the Literature

Seven studies (6 RCTs and one retrospective cohort study) addressed touch-based therapy. Five studies (four RCTs and one cohort) compared Qigong or traditional massage to no massage treatment (waitlist condition). ^25, 26, 33, 36, 40^ One RCT compared massage plus SI-based treatment with SI-based treatment alone,^32^ and one retrospective cohort compared attachment therapy plus massage with attachment therapy alone.^41^ Studies were conducted in the United States,^25, 26, 33, 36, 40^ Korea,^41^ and Thailand^32^ and had moderate^25, 33, 36^ and high risk of bias.^26, 32, 40, 41^ Three RCTs were also reported in our 2011 review.^26, 32, 33^

One team of investigators has published most of the literature in this area, and the extent of overlap among participants in these studies is unclear.^25, 26, 33, 40, 42^ Studies included approximately 439 children receiving treatment for 2 to 5 months. One study reported followup of participants 5 months after the end of treatment.^26^

#### Detailed Analysis

Massage Versus No Massage. Almost all of studies are from one group of investigators, and the participant overlap is unclear (Appendix F). Some used only parent-and teacher-rated outcomes, but others used standardized measures of autism symptoms, language, and adaptive functioning (e.g., CARS, Preschool Language Scale [PLS], Vineland Adaptive Behavior Scales [VABS]). Studies generally reported improvements related to sensory processing, autism symptoms, and parent stress in both treatment and control groups over the course of 5 months of either parent or parent + therapist-delivered intervention, with treatment groups improving significantly more than controls. Some studies also examined the moderating influence of baseline variables, such as parent stress or autism severity, which are important confounds to explore. The difficulty differentiating populations in these studies limits the strength of evidence for their findings, although results seem promising regarding a sensory-focused intervention that can be delivered within the home environment with minimal risk of harms.

As noted, four RCTs (three with moderate risk of bias^25, 33,36^ and one with a high risk of bias^26^) and one retrospective cohort study^40^ (high risk of bias) had unclear participant overlap and compared children who received Qigong Sensory Training (QST) to wait-listed controls or usual care. In one study comparing children who received QST to children receiving treatment as usual,^25^ parents participated in seven sessions instructing them in the basics of Qigong. Most children concurrently attended early intervention preschools for 5–10 hours a week, and participants included an unknown number of sibling pairs. Children receiving QST significantly improved from baseline on teacher and parent ratings of autism symptoms as well as parent ratings of sensory challenges, self-regulation skills, communication skills, and maladaptive behaviors (p values ≤0.05). When compared with the waitlist control group, improvements were significantly larger for autism symptoms (PDDBI), parent stress, and sensory/self-regulation challenges (Sensory and Self-Regulation Checklist), with medium to large effect sizes. Changes in teacher-rated ASD symptoms (Autism Behavior Checklist [ABC]) were not significantly different between treatment and control groups. Some children (N not clear) received parent + therapist-delivered massage (dual group) while others received only parent-delivered massage. While both groups improved on all measures from baseline, children in the dual group had greater improvements than those in the parent-only group (p values=ns).

Participants in a second RCT included five sibling pairs.^26^ Children in the treatment group also had more severe challenging behaviors and sensory impairments at baseline. Children who received QST significantly improved on parent- and teacher-reported measures of autism symptoms, maladaptive behavior, communication skills, and sensory functioning from baseline, whereas children in the control group improved only on teacher measures of maladaptive behaviors (p values≤0.05). Children in the treatment group improved significantly more on teacher-rated measures of behavior and language (PDDBI, ABC) but not in maladaptive behavior compared with the control group. Children who received QST also improved more on all parent-rated measures of behavior and sensory processing (PDDBI, SSC) than did children in the control group.^26^ Parent-rated data on 19 treatment group participants still available for data collection showed that gains were maintained 5-months after the end of treatment.

A third RCT from the same group compared waitlisted controls to children who received five months of a QST Dual Program (parent + therapist-delivered massage).^36^ Baseline variables and attrition rates were similar across groups. Children in both groups showed improvement over time in most domains, although control group improvements were generally of smaller magnitude than the treatment group. Post-hoc analyses revealed specific treatment effects on parent-reported but not clinician-rated measures: autism symptoms, receptive (but not expressive) language, sensory processing, and parent stress improved more in the treatment group compared with control (p values <0.01). Group differences in social and living skills were not significant.

A final study from this group, with high risk of bias and unclear participant overlap with prior studies, retrospectively compared outcomes for children who either received QST for 5-months or were waitlisted controls.^40^ Participants in the treatment groups received two varying levels of intervention (Home Program—parent only massage; Dual Program—parent + therapist-delivered massage), and outcome measures were reported by both parents and therapists using different reporting strategies (questionnaire versus observation). Participants in the treatment groups showed significant improvements in tactile defensiveness, self-regulation skills, and parent stress levels compared with controls.

Massage + SI-Based Treatment Versus SI-Based Treatment Alone. One RCT with high risk of bias (included in the 2011 review) investigated 8 weeks of SI-based therapy compared with SI-based therapy plus traditional Thai massage.^32^ Children in the intervention group (but not the control group) had significantly improved parent ratings of anxiety and conduct both relative to baseline and relative to controls (p≤0.03). Children in both conditions had improved sleep as well as teacher ratings of conduct, attention, and activity level, and these ratings did not significantly differ across treatment groups. Participants in the treatment group had fewer symptoms of hyperactivity and sleep problems at baseline.^32^

Massage + Attachment Therapy Versus Attachment Therapy Alone. One retrospective cohort study (high risk of bias) investigated the impact of massage therapy with and without attachment therapy on social maturity, ASD symptoms, and mother-child attachment.^41^ The attachment program involved two hours per day of play activities to promote mother-child interactions, five days per week, for four months. Participants in the experimental group also received one hour of massage therapy per week from trained nurses. The nurses encouraged mothers to talk and sing to children and also demonstrated massage techniques. Social maturity on the observer-rated Vineland Social Maturity Scale improved in the massage group compared with the attachment only group (p=0.005), but CARS scores did not differ significantly between groups.

### Additional Studies

#### Key Points

- One study addressed tactile stimulation exercises and one addressed weighted blankets. These studies provided insufficient data to draw conclusions (insufficient strength of evidence).

#### Overview of the Literature

One RCT of a tactile input task conducted in the United States had high risk of bias and included 34 children between 4 and 14 years old.^29^ Treatment duration was 24 to 48 hours. Another RCT with low risk of bias conducted in the United Kingdom included 54 children between 5 and 16 years of age.^28^ Treatment duration was 2 weeks. Both studies had followup immediately post-treatment.

#### Detailed Analysis

Other interventions with sensory-related components reported few significant differences between treatment groups (Appendix G).

Tactile Input. One RCT (high risk of bias) examined the impact of a tactile-based task on the ability of 34 children with autism to learn a novel task.^29^ Participants included children who could not complete standardized cognitive or language evaluations. Children either participated in a tactual-kinesthetic experience (a “hands on” learning activity) or observed someone else performing the activity. Stimuli were presented across two sessions, 24–48 hours apart. Children in the hands-on participation group scored significantly better on ratings of perceived ease of implementing the learning task than children in the control condition (p values ≤ 0.05).

Weighted Blankets. One crossover RCT with moderate risk of bias examined the impact of a weighted blanket on sleep disturbance in children with severe problems with sleep onset or maintenance.^28^ Children used a control or weighted blanket for 12–16 days and then switched. No significant differences emerged on any of the variables of interest related to sleep onset/quality, child behavior, or family functioning. Regardless of baseline factors such as sensory sensitivities, autism severity, and sleep problems, parents were more likely to rate their children as calmer and sleeping better when using the weighted blanket, despite a lack of physiological evidence to support this. Additionally, both children and parents reported preferring the weighted blanket. Investigators reported that one child developed a rash that may have been due to the blanket (resolved in 2 days).

## Key Question 2 Modifiers of Treatment Outcomes

Few studies were likely adequately powered to assess modifiers of effects, and few studies reported potential modifiers. While we sought characteristics of interventions, providers, parents, or children that may modify treatment effects, studies reported only child and family characteristics. We present findings as reported in each study below as potential indicators of characteristics that may affect outcomes.

Child Characteristics. One study of an environmental enrichment-based approach reported that while more children in the treatment group compared with the control group shifted their diagnostic classification on the ADOS-2 from “autism” to “autism spectrum,” all children across both groups continued to meet the cut-offs for ASD, making it difficult to interpret the clinical significance of the findings. Baseline language and cognitive skills scores contributed to the majority of the variance when predicting which children in the treatment group would shift diagnostic cut-offs on the ADOS.^24^ In another RCT comparing filtered and unfiltered music, participants whose parents rated them as having improved hearing sensitivity were more likely to show an increase in their sharing behaviors during a semi-structured play evaluation.^18^ An RCT comparing home-based Qigong massage therapy to waitlisted controls found that children with fewer sensory symptoms and fewer difficulties with self-regulation benefited more from the treatment program.^26^ In other studies of massage, treatment effects on child behaviors and language were not moderated by baseline ASD severity as measured on the CARS,^36^ and interactions between self-regulation skills and tactile sensitivity or tactile sensitivity and parenting stress were not significant.^40^

In a music therapy RCT, analyses based on diagnostic subtype indicated that participants with diagnoses of autism had significant improvement in the CARS domain of nonverbal communication (p = .008) compared with children in the control group with diagnoses of autism.^37^ The study reported no other significant differences based upon either participant subtype or treatment received. Finally, one study comparing weighted blankets and regular blankets reported that no baseline factors related to autism severity, sleep problems, or sensory sensitivities modified parents’ ratings of children’s sleep quality.^28^

Family Characteristics. Although many studies collected parent report of child functioning, only one asked parents about their own functioning. One study of massage assessed parental stress levels and found that children in the treatment group had greater improvements in autism symptoms and overall behavior if their parents were less stressed at intake.^25^ This would be an important avenue of future research, given that parental and family variables may influence how parents perceive children’s functioning and subsequently complete questionnaires. Another study evaluated the quality of parent-child relationships as a potential modifier but did not find any treatment effects.^27^

## Key Question 3 Time to Effect of Interventions

No study examined the time to effect for sensory related interventions.

## Key Question 4 Evidence That Effects Measured at the End of Treatment Predict Long-Term Functional Outcomes

Only two studies conducted a followup after treatment ended. Followup occurred at two and five months in each study.^26, 38^ Additionally, many of the outcome measures were based upon parent reports rather than using standardized interactive assessments. Therefore, little existing evidence at this time contributes to predicting long-term functional outcomes.

## Key Question 5 Effectiveness Across Environments or Contexts

We did not identify studies addressing this outcome directly. Many studies collected parent or teacher report of sensory sensitivities as a way of assessing functioning in multiple environments, but these assessments generally did not evaluate functioning within multiple specific contexts.

## Key Question 6 Drivers of Treatment Outcomes

We did not identify any studies addressing this KQ.