# References

1 American Psychiatric Association. Diagnostic and Statistical Manual of Mental Disorders. V ed. Washington DC: American Psychiatric Association 2013.
2 Baranek GT. Efficacy of sensory and motor interventions for children with autism. J Autism Dev Disord. 2002 Oct;32(5):397–422.12463517
3 Case-Smith J, Weaver LL, Fristad MA. A systematic review of sensory processing interventions for children with autism spectrum disorders. Autism: The International Journal of Research & Practice. 2015;19(2):133–48 16p. doi: 10.1177/1362361313517762.24477447
4 State of the Science: A Roadmap for Research in Sensory Integration. American Journal of Occupational Therapy. 2015;69:(6)1–7 p. doi: 10.5014/ajot.2015.019539.
5 Schaaf RC. Interventions that address sensory dysfunction for individuals with autism spectrum disorders: Preliminary evidence for the superiority of sensory integration compared to other sensory approaches. Evidence-based practices and treatments for children with autism.: Springer Science + Business Media, New York, NY; 2011:245–73.
6 Barton EE, Reichow B, Schnitz A, . A systematic review of sensory-based treatments for children with disabilities. Res Dev Disabil. 2015 Feb;37:64–80. doi: 10.1016/j.ridd.2014.11.006.25460221
7 Ospina MB, Krebs Seida J, Clark B, . Behavioural and developmental interventions for autism spectrum disorder: a clinical systematic review. PLoS One. 2008;3(11):e3755. doi: 10.1371/journal.pone.0003755 .19015734
8 Seida JK, Ospina MB, Karkhaneh M, . Systematic reviews of psychosocial interventions for autism: an umbrella review. Dev Med Child Neurol. 2009 Feb;51(2):95–104. doi: DMCN3211 [pii] 10.1111/j.1469-8749.2008.03211.x .19191842
9 Parr J. Autism BMJ Clin Evid. 2010;2010.
10 Wan Yunus F, Liu KP, Bissett M, . Sensory-Based Intervention for Children with Behavioral Problems: A Systematic Review. J Autism Dev Disord. 2015 Nov;45(11):3565–79. doi: 10.1007/s10803-015-2503-9.26092640
11 Myers SM, Johnson CP. Management of children with autism spectrum disorders. Pediatrics. 2007 Nov;120(5):1162–82. doi: peds.2007–2362 [pii] 10.1542/peds.2007–2362 .17967921
12 National Autism Center. National Standards Report National Autism Center. Randolph, MA: National Autism Center: 2009. http://www.nationalautismcenter.org/pdf/NAC%20Standards%20Report.pdf
13 National Research Council. Committee on Educational Interventions for Children with Autism. Educating Children with Autism Washington DC: National Academies Press; 2001. http://www.nap.edu/openbook.php?record_id=10017&page=R2
14 Warren Z, Veenstra-VanderWeele J, Stone W, Bruzek JL, Nahmias AS, Foss-Feig JH, Jerome RN, Krishnaswami S, Sathe NA, Glasser AM, Surawicz T, McPheeters ML. Therapies for Children With Autism Spectrum Disorders. Comparative Effectiveness Review No. 26. (Prepared by the Vanderbilt Evidence-based Practice Center under Contract No. 290-2007-10065-I.) AHRQ Publication No. 11-EHC029-EF. Rockville, MD: Agency for Healthcare Research and Quality. April 2011. www.effectivehealthcare.ahrq.gov/reports/final.cfm.
15 Schaaf RC, Schoen SA, May-Benson TA, . State of the Science: A Roadmap for Research in Sensory Integration. Am J Occup Ther. 2015 Nov–Dec;69(6):6906360010p1–7. doi: 10.5014/ajot.2015.019539.
16 Methods Guide for Effectiveness and Comparative Effectiveness Reviews. AHRQ Publication No. 10(14)-EHC063-EF. Rockville, MD: Agency for Healthcare Research and Quality. January 2014. Chapters available at: www.effectivehealthcare.ahrq.gov
17 Weitlauf AS, McPheeters ML, Peters B, Sathe N, Travis R, Aiello R, Williamson E, Veenstra-VanderWeele J, Krishnaswami S, Jerome R, Warren Z. Therapies for Children With Autism Spectrum Disorder: Behavioral Interventions Update. Comparative Effectiveness Review No. 137. (Prepared by the Vanderbilt Evidence-based Practice Center under Contract No. 290-2012-00009-I.) AHRQ Publication No. 14-EHC036-EF. Rockville, MD: Agency for Healthcare Research and Quality; August 2014. www.effectivehealthcare.ahrq.gov/reports/final.cfm.
18 Porges SW, Bazhenova OV, Bal E, . Reducing auditory hypersensitivities in autistic spectrum disorder: preliminary findings evaluating the listening project protocol. Front Pediatr. 2014;2:80. doi: 10.3389/fped.2014.00080.25136545
19 Srinivasan SM, Eigsti I-M, Gifford T, . The effects of embodied rhythm and robotic interventions on the spontaneous and responsive verbal communication skills of children with Autism Spectrum Disorder (ASD): A further outcome of a pilot randomized controlled trial. Research in Autism Spectrum Disorders. 2016;27:73–87. doi: http://dx.doi.org/10.1016/j.rasd.2016.04.001.27668011
20 Srinivasan SM, Eigsti IM, Neelly L, . The effects of embodied rhythm and robotic interventions on the spontaneous and responsive social attention patterns of children with Autism Spectrum Disorder (ASD): A pilot randomized controlled trial. Res Autism Spectr Disord. 2016 Jul;27:54–72. doi: 10.1016/j.rasd.2016.01.004.27453721
21 Schaaf RC, Benevides T, Mailloux Z, . An intervention for sensory difficulties in children with autism: a randomized trial. J Autism Dev Disord. 2014 Jul;44(7):1493–506. doi: 10.1007/s10803-013-1983-8.24214165
22 Pfeiffer BA, Koenig K, Kinnealey M, . Effectiveness of sensory integration interventions in children with autism spectrum disorders: a pilot study. Am J Occup Ther. 2011 Jan–Feb;65(1):76–85.21309374
23 Woo CC, Leon M. Environmental enrichment as an effective treatment for autism: a randomized controlled trial. Behav Neurosci. 2013 Aug;127(4):487–97. doi: 10.1037/a0033010.23688137
24 Woo CC, Donnelly JH, Steinberg-Epstein R, . Environmental enrichment as a therapy for autism: A clinical trial replication and extension. Behav Neurosci. 2015 Aug;129(4):412–22. doi: 10.1037/bne0000068.26052790
25 Silva LM, Schalock M, Gabrielsen K. Early intervention for autism with a parent-delivered Qigong massage program: a randomized controlled trial. Am J Occup Ther. 2011 Sep–Oct;65(5):550–9.22026323
26 Silva LM, Schalock M, Ayres R, . Qigong massage treatment for sensory and self-regulation problems in young children with autism: a randomized controlled trial. Am J Occup Ther. 2009 Jul–Aug;63(4):423–32.19708471
27 Thompson GA, McFerran KS, Gold C. Family-centred music therapy to promote social engagement in young children with severe autism spectrum disorder: a randomized controlled study. Child Care Health Dev. 2014 Nov;40(6):840–52. doi: 10.1111/cch.12121.24261547
28 Gringras P, Green D, Wright B, . Weighted blankets and sleep in autistic children--a randomized controlled trial. Pediatrics. 2014 Aug;134(2):298–306. doi: 10.1542/peds.2013-4285.25022743
29 Latham SO, Stockman IJ. Effect of augmented sensorimotor input on learning verbal and nonverbal tasks among children with autism spectrum disorders. J Autism Dev Disord. 2014 Jun;44(6):1288–302. doi: 10.1007/s10803-013-1990-9.24234676
30 Kim J, Wigram T, Gold C. The effects of improvisational music therapy on joint attention behaviors in autistic children: a randomized controlled study. J Autism Dev Disord. 2008 Oct;38(9):1758–66. doi: 10.1007/s10803-008-0566-6 .18592368
31 Fazlioglu Y, Baran G. A sensory integration therapy program on sensory problems for children with autism. Percept Mot Skills. 2008 Apr;106(2):415–22.18556898
32 Piravej K, Tangtrongchitr P, Chandarasiri P, . Effects of Thai traditional massage on autistic children’s behavior. J Altern Complement Med. 2009 Dec;15(12):1355–61. doi: 10.1089/acm.2009.0258 .20001837
33 Silva LM, Cignolini A, Warren R, . Improvement in sensory impairment and social interaction in young children with autism following treatment with an original Qigong massage methodology. Am J Chin Med. 2007;35(3):393–406. doi: S0192415X07004916 [pii].17597498
34 Corbett BA, Shickman K, Ferrer E. Brief report: the effects of Tomatis sound therapy on language in children with autism. J Autism Dev Disord. 2008 Mar;38(3):562–6. doi: 10.1007/s10803-007-0413-1 .17610057
35 Mudford OC, Cross BA, Breen S, . Auditory integration training for children with autism: no behavioral benefits detected. Am J Ment Retard. 2000 Mar;105(2):118–29.10755175
36 Silva LM, Schalock M, Gabrielsen KR, . Early Intervention with a Parent-Delivered Massage Protocol Directed at Tactile Abnormalities Decreases Severity of Autism and Improves Child-to-Parent Interactions: A Replication Study. Autism Res Treat. 2015;2015:904585. doi: 10.1155/2015/904585.25878901
37 Gattino GS, dos Santos Riesgo R, Longo D, . Effects of relational music therapy on communication of children with autism: A randomized controlled study. Nordisk tidskrift for musikkterapi - Nordic Journal of Music Therapy. 2011 2015-12-09;20(2):142–54. doi: http://dx.doi.org/10.1080/08098131.2011.566933; 2011-14788-003.
38 Ghasemtabar SN, Hosseini M, Fayyaz I, . Music therapy: An effective approach in improving social skills of children with autism. Adv Biomed Res. 2015;4:157. doi: 10.4103/2277-9175.161584.26380242
39 Iwanaga R, Honda S, Nakane H, . Pilot study: efficacy of sensory integration therapy for Japanese children with high-functioning autism spectrum disorder. Occup Ther Int. 2014 Mar;21(1):4–11. doi: 10.1002/oti.1357.23893373
40 Silva L, Schalock M. Treatment of tactile impairment in young children with autism: results with qigong massage. Int J Ther Massage Bodywork. 2013;6(4):12–20.24298297
41 Lee HK. Effects of Massage and Attachment Promotion Program on Social Maturity, Child Autism and Attachment of Children with Autism and Their Mothers. J Korean Acad Child Health Nurs. 2008 1;14(1):14–21.
42 Patil RR. MMR vaccination and autism: learnings and implications. Hum Vaccin. 2011 Feb;7(2):281–2.21343697
43 Lee MS, Kim JI, Ernst E. Massage therapy for children with autism spectrum disorders: a systematic review. J Clin Psychiatry. 2011 Mar;72(3):406–11. doi: 10.4088/JCP.09r05848whi.21208598
44 Sinha Y, Silove N, Hayen A, . Auditory integration training and other sound therapies for autism spectrum disorders (ASD). Cochrane Database Syst Rev. 2011(12):CD003681. doi: 10.1002/14651858.CD003681.pub3.22161380
45 Geretsegger M, Holck U, Gold C. Randomised controlled trial of improvisational music therapy’s effectiveness for children with autism spectrum disorders (TIME-A): study protocol. BMC Pediatr. 2012;12:2. doi: 10.1186/1471-2431-12-2.22221670
46 Weaver LL. Effectiveness of Work, Activities of Daily Living, Education, and Sleep Interventions for People With Autism Spectrum Disorder: A Systematic Review. Am J Occup Ther. 2015 Sep–Oct;69(5):6905180020p1–p11. doi: 10.5014/ajot.2015.017962.
47 Tanner K, Hand BN, O’Toole G, . Effectiveness of Interventions to Improve Social Participation, Play, Leisure, and Restricted and Repetitive Behaviors in People With Autism Spectrum Disorder: A Systematic Review. Am J Occup Ther. 2015 Sep–Oct;69(5):6905180010p1–p12. doi: 10.5014/ajot.2015.017806.
48 Leong HM, Carter M, Stephenson J. Systematic review of sensory integration therapy for individuals with disabilities: Single case design studies. Res Dev Disabil. 2015 Dec;47:334–51. doi: 10.1016/j.ridd.2015.09.022.26476485
49 Lang R, O’Reilly M, Healy O, . Sensory integration therapy for autism spectrum disorders: A systematic review. Research in Autism Spectrum Disorders. 2012 2015-02-24;6(3):1004–18. doi: http://dx.doi.org/10.1016/j.rasd.2012.01.006; 2012-13564-007.
50 Watling R, Hauer S. Effectiveness of Ayres Sensory Integration((R)) and Sensory-Based Interventions for People With Autism Spectrum Disorder: A Systematic Review. Am J Occup Ther. 2015 Sep–Oct;69(5):6905180030p1–p12. doi: 10.5014/ajot.2015.018051.
51 Misic B, Doesburg SM, Fatima Z, . Coordinated Information Generation and Mental Flexibility: Large-Scale Network Disruption in Children with Autism. Cereb Cortex. 2015 Sep;25(9):2815–27. doi: 10.1093/cercor/bhu082.24770713
52 Geretsegger M, Elefant C, Mossler KA, . Music therapy for people with autism spectrum disorder. Cochrane Database Syst Rev. 2014 Jun 17(6):CD004381. doi: 10.1002/14651858.CD004381.pub3.
53 Section On C, Integrative M, Council on Children with D, . Sensory integration therapies for children with developmental and behavioral disorders. Pediatrics. 2012 Jun;129(6):1186–9. doi: 10.1542/peds.2012-0876.22641765
54 Watling RK, KP; Davies PL; Schaaf R. Occupational Therapy Practice Guidelines for Children and Adolescents With Challenges in Sensory Processing and Sensory Integration AOTA. 2011.