# Methods

In this chapter, we briefly outline the procedures that we used to produce a Comparative Effectiveness Review (CER) update addressing interventions targeting sensory challenges for children with autism spectrum disorder (ASD). Appendix A includes a more detailed discussion of our methods. These procedures follow the methods outlined in the Agency for Healthcare Research and Quality (AHRQ) Effective Health Care Program Methods Guide for Effectiveness and Comparative Effectiveness Reviews.^16^

## Topic Surveillance and Review Protocol

The topic for the original report^14^ was nominated by Autism Speaks in a public process using the Effective Health Care Web site. AHRQ published an update addressing behavioral interventions in 2014.^17^ We conducted a surveillance process to assess the need to update the report by contacting topic experts about the relevance of the Key Questions (KQs) and new evidence that may address them. All members of the research team were required to submit information about potential conflicts of interest before initiation of the work. No members of the review team had any conflicts.

In consultation with clinical experts and stakeholders, and based on our preliminary scan of the literature and surveillance findings, we focused the review update on approaches to address sensory challenges and medical approaches (reported in a separate update). These areas reflect both areas of clinical relevance and sufficient newly published literature for a review update. Given the different major emphases of these interventions (i.e., sensory processing/integration abilities and challenging behaviors) and subsequent differences in study populations, we report findings in two separate reviews.

Based also on the surveillance process and discussions with stakeholders, we revised the KQ addressed in the 2011 report to reflect the focus on medical and sensory approaches specifically. We also eliminated a question on approaches for children at risk for ASD as such children are unlikely to be included in studies in the target areas for this review update.

After review from AHRQ, the questions and framework were posted online for public comment. No changes to the questions or framework were recommended. We identified technical experts on the topic to provide assistance during the project. The Technical Expert Panel (TEP), representing the fields of pediatrics and developmental pediatrics, psychiatry, family medicine, and occupational therapy and allied health, contributed to the AHRQ’s broader goals of (1) creating and maintaining science partnerships as well as public-private partnerships and (2) meeting the needs of an array of potential users of its products. Thus, the TEP was both an additional resource and a sounding board during the project. The TEP included seven members serving as technical or clinical experts. To ensure robust, scientifically relevant work, TEP members participated in conference calls to:

- Help to refine the analytic framework and KQ at the beginning of the project;
- Discuss inclusion/exclusion criteria; and
- Assist with determining key interventions and outcomes of interest.

The final protocol was posted to the AHRQ Effective Health Care Web site and registered in the PROSPERO international register of systematic reviews (ID#: CRD42016033941).

## Literature Search Strategy

### Search Strategy

To ensure comprehensive retrieval of relevant studies of therapies for children with ASD, we used four key databases: the MEDLINE^®^ medical literature database via the PubMed^®^ interface; EMBASE (Excerpta Medica Database), an international biomedical and pharmacological literature database via the Ovid^®^ interface; the Cumulative Index of Nursing and Allied Health Literature (CINAHL), and PsycINFO^®^. Search strategies for KQs applied a combination of controlled vocabulary (Medical Subject Headings [MeSH] and Emtree headings) to focus specifically on interventions targeting sensory challenges in children with ASD and harms of interventions (Appendix B). We restricted literature searches for KQs to studies published from 2010 to September 2016 to reflect literature available since the publication of the 2011 review.

#### Gray Literature

We searched Web sites of organizations likely to conduct research, issue guidance, or generate policies for ASD (e.g., Autism Speaks, the American Academy of Child and Adolescent Psychiatry) to inform the review’s background and discussion sections. We searched government and regulatory agency Web sites for contextual information on benefits and harms of ASD interventions. We searched ClinicalTrials.gov, the International Standard Randomized Controlled Trials Number (ISRCTN) registry, and other trial registries for information about relevant ongoing trials and to confirm that we have obtained available publications of results from completed trials.

### Inclusion and Exclusion Criteria

Table 1 outlines inclusion criteria. We required that eligible randomized controlled trials (RCTs) have a total minimum sample size of 10. We required a higher minimum sample size (n=20) for other comparative studies as they typically have fewer controls for bias than RCTs. We recognize that these study design criteria excluded single-subject or single-case experimental designs that have been used to study interventions targeting sensory challenges. These studies are challenging to incorporate in a meaningful way in comparative effectiveness reviews, which attempt to evaluate the effectiveness of interventions at the population level. To mitigate the exclusion of such studies; however, we include summaries of recent reviews that have included such studies and discuss our findings in light of those in other reviews (see Findings in Relation to What Is Already Known).

Table 1 Inclusion criteria

Category | Criteria
Study Population | Children ages 2–12 with ASD (mean age plus standard deviation is ≤ 12 years and 11 months)
Publication Languages | English only
Admissible Evidence (study design and other criteria) | Admissible designs Randomized controlled trials, prospective and retrospective cohort studies with comparison groups, and nonrandomized controlled trials Other criteria Original research studies published from 2010—present and not addressed in prior reviews Studies must have relevant population and ≥20 participants with ASD (non-RCTs) or at least 10 total participants (RCTs) Studies must address one or more of the following for ASD: -Outcomes of interest -Treatment modality of interest -Predictors or drivers of treatment outcomes (e.g., biomarkers, clinical changes) -Maintenance of outcomes across environments or contexts -Sufficiently detailed methods and results to enable data extraction -Reporting of outcome data by target population or intervention

ASD=autism spectrum disorder; RCT=randomized controlled trial

We included studies published in English only. In the opinion of our content experts, much of the relevant literature on ASD is published in English. We focused the review on children between 2 and 12 years of age. We chose to limit the age range to this span because a) diagnosis of ASD earlier than age 2 is less established and b) adolescents likely have substantially different challenges and would warrant different interventions than children in the preschool, elementary and middle school age groups. Studies also included only children with a diagnosis of ASD (or data reported separately for children with ASD).

### Study Selection

Two reviewers separately evaluated the abstracts of studies identified in our searches for KQs for inclusion or exclusion, using an Abstract Review Form (Appendix C). If one reviewer concluded that the article could be eligible for the review based on the abstract, we retained it. Following abstract review, two reviewers independently assessed the full text of each included study using a standardized form (Appendix C) that included questions stemming from our inclusion and exclusion criteria. A senior reviewer resolved disagreements between reviewers. Appendix D includes a list of excluded studies and the reasons for exclusion. Data extracted for each study are available via the Systematic Review Data Repository (http://srdr.ahrq.gov/).

### Data Extraction

We designed extraction forms to provide sufficient information to enable readers to understand the studies and to determine their quality; we gave particular emphasis to essential information related to the KQs. Team data extractors shared the task of initially entering information into the evidence tables. A second team member also reviewed the articles and edited all initial entries for accuracy, completeness, and consistency. A senior reviewer reconciled disagreements concerning the information reported.

## Data Synthesis

Studies were too heterogeneous to allow for meta-analyses. We summarized data for Key Questions qualitatively using summary tables.

## Risk of Bias Assessment of Individual Studies

We evaluated the overall methodologic risk of bias of individual studies using the ASD-specific assessment approach developed and used in our prior reviews of interventions for ASD and informed by the Methods Guide for Effectiveness and Comparative Effectiveness Reviews.^16^ We developed this tool because standard risk of bias assessment tools (e.g., Cochrane risk of bias assessment) do not fully account for the complexity of interventions and populations represented in the ASD literature. Specifically, the tool includes questions to address diagnostic approaches and measures of treatment fidelity that may affect outcomes. The tool has not been formally validated.

Two senior investigators assessed each included study independently with disagreements resolved through discussion. Appendix C includes our risk of bias assessment form, and Appendix E includes the risk of bias ratings for each study. Appendix A includes additional details about our risk of bias approach.

## Determining Overall Risk of Bias Ratings

We used the thresholds we established in prior reviews to assess overall high, medium or low risk of bias. We assessed the risk of bias based upon the study-defined primary outcome(s). We assessed each domain described above individually and considered the individual ratings to determine an overall quality assessment of low, moderate, or high risk of bias. Appendix A includes additional details.

## Applicability

We assessed the applicability of findings reported in the included literature addressing our KQs to the general population of children with ASD by determining the population, intervention, comparator, and setting in each study and developing an overview of these elements for each intervention category. We anticipated that areas in which applicability would be especially important to describe would include ASD severity, comorbidities, age at treatment, and intervention characteristics such provider, dosing/intensity, and setting. Applicability tables for each KQ are in Appendix F.

## Strength of the Body of Evidence

The assessment of the literature is done by considering both the observed effectiveness of interventions and the confidence that we have in the stability of those effects in the face of future research (see Appendix A for full details). The degree of confidence that the observed effect of an intervention is unlikely to change is presented as strength of evidence. Methods for applying strength of evidence assessments are established in the Methods Guide for Effectiveness and Comparative Effectiveness Reviews^16^ and are based on consideration study limitations, consistency in direction of the effect, directness in measuring intended outcomes, precision of effect, and reporting bias. Strength of evidence is assessed separately for major intervention-outcome pairs and incorporates data from the entire body of reviewed evidence on behavioral interventions (i.e., comparative studies—both RCTs and prospective and retrospective cohort studies—reported in the 2011 review^14^ and studies reported in the current review). The possible strength of evidence grades were:

- High: High confidence that the evidence reflects the true effect. Further research is unlikely to change estimates
- Moderate: Moderate confidence that the evidence reflects the true effect. Further research may change our confidence in the estimate of effect and may change the estimate
- Low: Low confidence that the evidence reflects the true effect. Further research is likely to change confidence in the estimate of effect and is also likely to change the estimate
- Insufficient: Evidence is either unavailable or does not permit a conclusion.

## Peer Review and Public Commentary

Researchers and clinicians with expertise in treating children with ASD and individuals representing stakeholder and user communities provided external peer review of this report. The draft report was posted on the AHRQ Web site for 4 weeks to elicit public comment. We addressed all reviewer comments, revised the text as appropriate, and documented changes and revisions to the report in a disposition of comments report that will be made available 3 months after AHRQ posts the final review on the AHRQ Web site.