# Introduction

## Background

Autism spectrum disorder (ASD) is a neurodevelopmental disorder broadly defined by impaired social communication as well as restricted or repetitive patterns of behavior and interest. As defined by the Diagnostic and Statistical Manual of Mental Disorders, Fifth edition (DSM-5), specific features of ASD include deficits in social and emotional reciprocity (e.g., atypical social approaches, conversational impairment, atypical sharing of interests, attention, and affect); deficits in nonverbal communication (e.g., poorly integrated verbal and nonverbal communication, atypical body-language and gesture use, deficits in use and understanding of nonverbal communication); and deficits in maintaining appropriate relationships (e.g., challenges with peer interest, vulnerabilities forming friendships, difficulties adjusting behavior to suit social contexts) as well as restricted and repetitive patterns of behavior such as stereotyped speech, motor movements, or use of objects; excessive adherence to routine or insistence on sameness; intense interest patterns; and atypical sensory interests or responses.^1^ Symptoms of the disorder impair and limit everyday functioning and are thought to be evident in early childhood, although they may not be fully evident until later ages. Although not a core symptom, many children with ASD may also have significant cognitive impairment.

Children with ASD may experience impairments in processing sensory stimuli, including intense interests in or aversion to certain types of sensory input; while somewhat challenging to operationalize, quantify, and measure clinically, estimates of impairments related to sensory processing have ranged from 42 percent to 88 percent of people with ASD and include both hyper- and hypo-responsiveness.^2–4^ Though sensory challenges are common and impairing features of ASD for many individuals, the exact nature of sensory integration in the development and lifespan trajectory is less understood. The field has historically lacked accepted frameworks for diagnosing sensory challenges (e.g., not part of DSM diagnostic criteria until DSM-5) and developing responsive interventions.^2, 3, 5, 6^

### Treatment of ASD

The manifestation and severity of symptoms of ASD differ widely, and treatments include a range of behavioral, psychosocial, educational, medical, and complementary approaches^7–10^ that vary by a child’s age and developmental status. The goals of treatment for ASD typically focus on improving core deficits in communication, social interactions, or restricted behaviors, as changing these fundamental deficits may help children develop greater functional skills and independence.^11^ Treatment frequently is complicated by symptoms or comorbidities that may warrant targeted intervention. There is no cure for ASD and no global consensus on which intervention is most effective.^12, 13^ Individual goals for treatment vary for different children and may include combinations of behavioral therapies, educational therapies, medical and related therapies, approaches targeting sensory issues, and allied health therapies; parents may also pursue complementary and alternative medicine therapies.

#### Interventions Targeting Sensory Challenges

Increasingly, as reflected in their inclusion in the new DSM-5 diagnostic criteria, the sensory challenges associated with ASD have also become a target for specialized assessment and treatment. Sensory symptoms can involve both strong interests as well as strong aversions, with interventions commonly targeting aversions/challenges, meeting needs for sensory input within adaptive frameworks, or perceived processing deficits with the goal of improving people’s abilities to interact with their environments. For example, a child with ASD may have difficulty tolerating bright lights, clothing or food textures, specific noises (such as a baby crying), tasks of daily living (such as brushing hair or teeth), touch, or more idiosyncratic stimuli such as certain colors. These sensitivities can significantly interfere with children’s ability to care for themselves, leave the home, participate in school or other interventions, and be involved in social situations. Children may also display a hyperfocus on play or activities that involves a sensory component, sometimes referred to as ”sensory-seeking” or ”stimming” behaviors.

Sensory-focused interventions take a variety of forms and can be implemented by a variety of licensed professionals (such as occupational therapists), teachers, parents, and other providers. Such interventions are not consistently defined but typically involve the incorporation of sensory experiences (e.g., weighted clothing or materials, interventions that provide auditory sensations) to affect a variety of outcomes including adaptive behavior and language.

## Scope and Key Questions

### Scope of Review

This review updates findings reported in the 2011 Agency for Healthcare Research and Quality (AHRQ) review Therapies for Children with ASD^14^ with a focus on studies of interventions targeting sensory challenges. We defined interventions targeting sensory challenges in line with the DSM-5 definition and definitions used in other reviews of sensory-focused interventions.^2, 3^ DSM-5 classifies sensory challenges as a manifestation of the core symptom of restricted and repetitive patterns of behavior, interests, or activities. The DSM describes sensory challenges as “hyper- or hyporeactivity to sensory input, manifested through extreme responses to specific sounds or textures, excessive smelling or touching of objects, fascination with lights or spinning objects, and sometimes apparent indifference to pain, heat, or cold.”^1^ Interventions targeting sensory challenges are typically described as designed to provide controlled sensory experiences in order to encourage the modulation and integration of information from the environment, thus promoting adaptive responses to sensory inputs.

Though the field lacks broad consensus on a definition of sensory-focused approaches, interventions typically use sensory modalities to target behaviors that may be associated with sensory-related impairments.^3, 15^ We do not include studies of other approaches (e.g., educational interventions) that may address a sensory-related outcome in the current review. A companion review updating findings related to medical interventions is available on the AHRQ Effective Health Care Web site.

### Key Questions

We developed Key Questions (KQs) in consultation with Key Informants and the Task Order Officer. KQs were posted for review to the AHRQ Effective Health Care Web site.

KQs were as follows:

KQ1 Among children ages 2–12 with ASD, what is the comparative effectiveness (benefits and harms) of interventions targeting sensory challenges?
  a. What are the effects on core symptoms (e.g., deficits in social communication and interaction; restricted, repetitive patterns of behavior, interests, or activities including hyper- or hypo- reactivity to sensory input or unusual interest in sensory aspects of the environment) in the short term (<6 months)?
  b. What are the effects on commonly associated symptoms (e.g., motor, medical, mood/anxiety, irritability, and hyperactivity) in the short term (<6 months)?
  c. What are the longer term effects (≥6 months) on core symptoms (e.g., social deficits, communication deficits, and repetitive behaviors)?
  d. What are the longer term effects (≥6 months) on commonly associated symptoms (e.g., motor, medical, mood/anxiety, irritability, and hyperactivity)?
KQ2 Among children ages 2–12 with ASD, what are the modifiers of outcome for different interventions targeting sensory challenges?
  a. Is the effectiveness of the therapies reviewed affected by the frequency, duration, intensity, or dose of the intervention?
  b. Is the effectiveness of the therapies reviewed affected by co-interventions or prior treatment, or the training and/or experience of the individual providing the therapy?
  c. What characteristics (e.g., age, symptom severity), if any, of the child modify the effectiveness of the therapies reviewed?
  d. What characteristics, if any, of the family modify the effectiveness of the therapies reviewed?
KQ3 What is the time to effect of interventions targeting sensory challenges?
KQ4 What is the evidence that effects measured at the end of the treatment phase predict long-term functional outcomes of interventions targeting sensory challenges?
KQ5 Is the effectiveness of interventions targeting sensory challenges maintained across environments or contexts (e.g., people, places, materials)?
KQ6 What evidence supports specific components of treatment with interventions targeting sensory challenges as driving outcomes, either within a single treatment or across treatments?

### Categorization of Interventions

Interventions targeting sensory challenges may be broadly categorized by their core focus (e.g., environmental modification/adaptation, compensatory strategies, sensory processing, auditory integration). However, frequently these categories of sensory-related approaches include overlapping targets and intervention strategies, as well as unique and differing aspects of the same constructs. As such it is extremely challenging to identify definitively the category into which many offered interventions should be placed. With input from our clinical experts, we categorized approaches based on the core strategies used in each intervention. In some cases this approach grouped together interventions that may have used specific, manualized techniques with others that used only a subset of those techniques (e.g., Ayres-based sensory integration and sensory integration models that may have used some Ayres strategies). We note that no alternative approaches (e.g., considering Ayres-based approaches and other sensory integration approaches as separate categories) would have substantially changed our overall findings in terms of strength of evidence.

Based on the literature meeting criteria for this review, we categorized interventions as:

- Sensory integration-based (interventions using combinations of sensory and kinetic components such as materials with different textures, touch/massage, swinging and trampoline exercises, and balance and muscle resistance exercises to ameliorate sensory challenges)
- Environmental enrichment-based (interventions incorporating targeted exposure to sensory stimuli to promote tolerance of stimuli in other contexts)
- Auditory integration-based (interventions incorporating auditory components such as filtered sound to ameliorate sensory processing challenges via theorized re-training of aural pathways)
- Music therapy-based (interventions incorporating playing or singing music, or movement to music, to improve challenging behaviors and sensory difficulties)
- Touch/Massage-based (interventions incorporating touch-based approaches by a therapist or caregiver)
- Other (included interventions [tactile-based tasks, weighted blankets] not cleanly fitting into one of the broader categories).

We recognize that other approaches to categorizing interventions targeting sensory challenges could be used.

## Analytic Framework

The analytic framework (Figure 1) illustrates the population, interventions, outcomes, and adverse effects that guide the literature search and synthesis.

Figure 1 Analytic framework for review

ASD=autism spectrum disorder; KQ=Key Question

The analytic framework outlines the process by which families of children with ASD make and modify sensory-related treatment choices. Treatment effectiveness may be affected by factors related to the child (e.g., age, IQ) or the context of care. Ideally, treatment effects are seen both in the short term in clinical changes and in longer term or functional outcomes. Eventual outcomes of interest include adaptive independence appropriate to the abilities of the specific child, psychological well-being, appropriate academic engagement, social participation, and psychosocial adaptation. Circled numbers represent the report’s key questions; their placement indicates the points in the treatment process in which they are likely to arise.

## Uses of This Evidence Report

We anticipate that the report will be of value to clinicians who treat children with ASD, who can use the report to assess the evidence for different treatment strategies. In addition, this review will be of use to the National Institutes of Health, U.S. Centers for Disease Control and Prevention, Centers for Medicare & Medicaid Services, and the Health Resources and Services Administration–all of which have offices or bureaus devoted to child health issues and who may use the report to compare treatments and determine priorities for funding. This report can bring practitioners up to date about the current state of evidence related to interventions targeting sensory challenges, and it provides an assessment of the risk of bias of studies that aim to determine outcomes of sensory-related options for the management of ASD. It will be of interest to families affected by ASD because of the recurring need for families and their health care providers to make the best possible decisions among numerous options. We also anticipate it will be of use to private sector organizations concerned with ASD; the report can inform such organizations’ understanding of the effectiveness of treatments and the amount and quality of evidence available. Researchers can obtain a concise analysis of the current state of knowledge related to interventions targeting sensory challenges in ASD and of areas for future research.