# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project: Ms. Jessica Kimber was an invaluable resource for assistance with data extraction and checking, and helped to locate studies and track data. Ms. Katie Worley helped to extract data and create tables. Drs. Mamata Raj and Jeff Andrews assisted with screening studies and with risk of bias assessment. We sincerely appreciate their dedicated work as well as the input of our Task Order Officers; Associate Editor, Margaret Maglione; and Key Informants and Technical Experts.