# Discussion

## State of the Literature

We identified a total of 24 studies (20 randomized controlled trials [RCTs], 1 nonrandomized trial, 3 retrospective cohort studies) addressing interventions targeting sensory challenges in children with autism spectrum disorder (ASD). Three studies had low risk of bias,^22, 24, 37^ 10 had moderate,^19–21, 23, 25, 27, 28, 33–36^ and 11 had high risk (including one paper reporting 2 unique studies).^18, 26, 29–32, 38–41^ Most studies were small and used different outcome measures. Treatment length varied from two days to 10 months, with two studies reporting followup after the immediate intervention period.^26, 38^ Protocols involved either parents or therapists engaging in one-on-one or group interactions; one RCT used a robot-delivered approach.

Compared with our previous review, more studies were designed in ways that increased their strengths, including random assignment and tracking of attrition; stratification of assignment or matching based upon key baseline variables; blinded ratings; treatment fidelity protocols; tracking or controlling for concurrent interventions; and using standardized outcome measures or measures that incorporated parent-selected outcomes of importance such as goal attainment scaling. We also identified more evidence addressing sensory-integration-based, environmental enrichment, music therapy, and massage modalities in particular. Although more information is available, the lack of consistency in implementation, combined with generally small sample sizes and limited followup, makes it difficult to draw strong conclusions regarding treatment efficacy.

Similarly, many studies continued to rely upon parent report of symptoms, although others used unbiased ratings of behavior (such as actigraphy or standardized measures) as well. It will be important for future work to compare sensory-based interventions not only to treatment as usual, but to other interventions that involve engaged and active time with an adult, as did some studies in the current review.^22, 24, 41^ Additional research is needed that controls for environmental or social factors that could cloud our ability to draw conclusions regarding effects.

## Summary of Key Findings and Strength of the Evidence

### Key Question 1 Benefits and Harms of Interventions Targeting Sensory Challenges

#### Sensory Integration (SI)-Based Approaches

In four small, short-term studies, sensory-related outcomes improved in children receiving an SI-based intervention compared with those receiving usual care or other treatment (significant improvements in three of four studies addressing the outcome). We have low confidence in this conclusion (low strength of evidence). Motor skills outcomes were significantly improved in children receiving SI-based treatment compared with those receiving usual care or other treatment (significant improvements in three of three studies addressing the outcome). We have low confidence in this conclusion (low strength of evidence). Evidence was insufficient to draw conclusions regarding other comparisons and outcomes. Table 4 outlines these findings.

Table 4 Strength of the evidence for sensory integration-based interventions versus control approaches

Intervention/Outcome Study Design Risk of Bias and Number of Studies (N Total) | Study Limitations | Consistency | Directness | Precision | Reporting Bias | Finding Strength of Evidence Grade
Sensory Challenges RCT: 1 low,^22^ 1 moderate,^21^ 1 high^31^ (N=99) Retrospective Cohort: 1 high^39^ (N=20) | High | Inconsistent | Direct | Imprecise | Undetected | Low SOE for positive effects of sensory integration-based approaches on sensory challenges Significant improvements in sensory-related behaviors in treatment groups compared with control in 2 RCTs and one cohort study. No group differences in third RCT on parent-reported measure of sensory behaviors but significant improvement in treatment group in sensory-related goals; all studies were small and short-term
Motor Skills RCT: 1 low,^22^ 1 moderate^21^ (N=69) Retrospective cohort: 1 high^39^ (N=20) | High | Consistent | Direct | Imprecise | Undetected | Low SOE for positive effects of sensory integration on motor skills Significant improvements in treatment groups vs. control in 3 small studies

N=number; RCT=randomized controlled trial; SOE=strength of the evidence

#### Environmental Enrichment-Based Approaches

Two small RCTs of environmental enrichment examined the same protocol involving parent-led sensory stimulation exercises and reported improvements in ASD symptoms, receptive language, and nonverbal cognitive skills after 6 months of treatment.^23, 24^

We have low confidence in the conclusion that these approaches improved nonverbal cognitive skills (low strength of evidence). These enrichment approaches do not affect expressive language. We have low confidence in this conclusion (low strength of evidence). We could not make conclusions about effects on atypical sensory responses or receptive language as these outcomes were only addressed in one RCT^24^ (insufficient strength of evidence). Table 5 outlines these findings.

Table 5 Strength of the evidence for environmental enrichment interventions versus usual care

Intervention/Outcome Study Design Risk of Bias and Number of Studies (N Total) | Study Limitations | Consistency | Directness | Precision | Reporting Bias | Finding Strength of Evidence Grade
Nonverbal Cognitive Skills RCT: 1 low,^24^ 1 moderate^23^ (N=78) | High | Consistent | Direct | Imprecise | Undetected | Low SOE for positive effects of enrichment on IQ Significant improvements in IQ (Leiter) in children receiving enrichment compared with those receiving usual care in 2 small RCTs with short-term followup and high limitations given small sample size
Expressive Language RCT: 1 low,^24^ 1 moderate^23^ (N=78) | High | Consistent | Direct | Imprecise | Undetected | Low SOE for lack of effect of enrichment on expressive language No group differences in expressive language in 2 small RCTs with short-term followup and high limitations given small sample size

IQ=intelligence quotient; N=number; RCT=randomized controlled trial; SOE=strength of the evidence

#### Auditory Integration-Based Approaches

Two small, short-term RCTs of auditory integration-based approaches assessing language outcomes reported no significant differences between groups in receptive language outcomes;^34, 35^ one RCT (in a publication reporting 2 unique studies) reported significant parent-rated improvements in spontaneous speech.^18^ We have low confidence in the conclusion that these approaches do not improve language outcomes (low strength of evidence) (Table 6).

Table 6 Strength of the evidence for auditory integration-based interventions versus control approaches

Intervention/Outcome Study Design Risk of Bias and Number of Studies (N Total) | Study Limitations | Consistency | Directness | Precision | Reporting Bias | Finding Strength of Evidence Grade
Language RCT: 2 moderate,^34, 35^ 1 high^18^ (N=91) | High | Inconsistent | Direct | Imprecise | Undetected | Low SOE for lack of effects of auditory integration approaches on language No group differences in outcomes in 2 small crossover RCTs with short-term followup; parent-rated improvements in spontaneous speech in treatment group vs. control in a third RCT

N=number; RCT=randomized controlled trial; SOE=strength of the evidence

#### Music Therapy-Based Approaches

Five small studies addressing music therapy reported some significant effects on measures of behavior (social engagement, behavioral organization), verbal and nonverbal communication, and joint attention with music-based intervention compared with control interventions; however, studies used different protocols and addressed different outcomes

We could not make conclusions about the effects of music therapy approaches on any outcome given that studies had multiple comparators and addressed different outcomes (insufficient strength of evidence).

#### Massage-Based Approaches

As noted, five of seven massage studies were from one group of investigators, with unclear participant overlap.^25, 26, 32, 33, 36, 40^ These studies generally reported improvements related to sensory processing, autism symptoms, and parent stress in both treatment and control groups over the course of 5 months of either parent or parent + therapist-delivered intervention, with treatment groups improving significantly more than controls. The difficulty differentiating between these works limits the strength of evidence for their findings, although results seem promising regarding a sensory-focused intervention that can be delivered within the home environment with minimal risk of harms. Two additional studies assessed massage therapy plus attachment therapy compared with attachment therapy alone or massage plus SI-based treatment vs. SI-based treatment alone.^32, 41^

Massage improved sensory challenges and ASD symptom severity vs. no massage. Our confidence in this conclusion is low (low strength of evidence). Massage did not improve maladaptive behavior. Our confidence in this conclusion is low (low strength of evidence due to unclear extent of overlap among participants and high study limitations [unblinded ratings, diagnostic processes]).

We could not make conclusions about the effects of massage on language/communication outcomes given inconsistent findings and use of different outcome measures (insufficient strength of evidence). We could not make conclusions about longer-term outcomes (≥6 months) as only one study^26^ reported longer-term followup (insufficient strength of evidence). We could not make conclusions about effects on measures of daily living skills, also assessed in only one study^36^ (insufficient strength of evidence). Only one study compared massage plus SI-based treatment to SI-based treatment alone^32^ or attachment therapy plus massage with attachment therapy alone^41^ so we could not make conclusions about these studies (insufficient strength of evidence). Table 7 outlines these findings.

Table 7 Strength of the evidence for massage-based interventions versus waitlist control conditions

Intervention/Outcome Study Design Risk of Bias and Number of Studies (N Total) | Study Limitations | Consistency | Directness | Precision | Reporting Bias | Finding Strength of Evidence Grade
ASD Symptom Severity RCT: 2 moderate,^25, 36^ 1 high^26^ (N=191) | High | Consistent | Direct | Imprecise | Undetected | Low SOE for improvements in ASD symptom severity with massage vs. control in the short-term (<6 months) Significant group differences in all 3 studies; SOE is low given unclear overlap in participants and high study limitations
Sensory Challenges RCT: 2 moderate,^25, 36^ 1 high^26^ (N=191) Retrospective Cohort: 1 high^40^ (N=129) | High | Consistent | Direct | Imprecise | Undetected | Low SOE for positive effects on sensory challenges with massage vs. control in the short-term (<6 months) Significant group differences in all 4 studies; SOE is low given unclear overlap in participants and high study limitations
Maladaptive Behaviors RCT: 1 moderate,^25^ (N=42), 1 high^26^ (N=46) | High | Consistent | Direct | Imprecise | Undetected | Low SOE for no effect on maladaptive behaviors with massage vs. control in the short-term (<6 months) No significant group differences in 2 studies; SOE is low given unclear overlap in participants and high study limitations

N=number; RCT=randomized controlled trial; SOE=strength of the evidence

#### Additional Interventions

Additional interventions with sensory-related components (tactile stimulation exercises,^29^ weighted blankets^28^) reported few significant differences between treatment groups. These studies provided insufficient data to draw conclusions about any outcomes (insufficient strength of evidence).

### Other Key Questions

Few studies were likely adequately powered to assess modifiers of effects, and few studies reported potential modifiers. We did not identify studies addressing the time to effect of interventions; evidence that effects measured at the end of treatment predict long-term functional outcomes; effectiveness of treatments across environments or contexts (e.g., clinic, home, school); and drivers of treatment outcomes.

### Findings in Relation to What Is Already Known

We identified eleven recent (2010-present) systematic reviews addressing interventions targeting sensory challenges.^6, 10, 43–51^ Three reviews were not specific to children with ASD but included studies of individuals with developmental disabilities.^6, 10, 48^ As a number of these studies included children with ASD, we retained these reviews.

Reviews addressed comprehensive sensory integration approaches (typically clinic-based interventions using sensory-enhanced modalities to integrate sensory information and potentially ameliorate specific challenges or behaviors); “sensory-based” interventions targeting somatosensory or vestibular symptoms such as therapy balls, massage, and weighted vests; auditory integration; massage; and music therapy. Our findings generally align with these prior reviews of interventions. Reviews noted low to moderate support for sensory integration-based approaches and limited evidence for other approaches. Reviews consistently noted considerable heterogeneity, limited study quality/high risk of bias, limited followup, and lack of treatment fidelity. Reviews differentiating sensory integration approaches and more general “sensory-based” approaches reported better evidence from those studies that evaluated specific, typically manualized sensory integration modalities compared with sensory-based approaches. One review of auditory integration approaches reported no evidence of effectiveness. One review of music therapy reported promising findings related to improvements in social interaction and communication, and one addressing massage reported that limited evidence precluded conclusions. We provide more detailed summaries of these reviews below.

#### Reviews of Sensory Integration or Sensory-Based Approaches

One review evaluating interventions for sensory processing disorders in children with ASD included 15 single subject design studies, two RCTs, one non-randomized trial, and one case report addressed sensory integration (n=5 studies) or sensory-based interventions (n=14 studies).^3^ Six studies had scores of at a least 5 on the 10 point PEDro scale, and four reported higher level evidence on the Center for Evidence-Based Medicine scale. The review reported positive effects on children’s individualized goals (effect sizes ranging from 0.72 to 1.17) associated with sensory integration approaches but noted that durability and generalizability of effects was unclear. Evidence for sensory-based approaches was limited, and the review noted that studies suggest no support for weighted vests and little conclusive evidence for therapy balls or other multisensory inputs.

Another review addressing Ayres sensory integration (4 studies) and more general sensory-based interventions (18 studies) in children and adults with ASD reported similar results.^50^ The studies addressing sensory integration included 133 children, and reviewers noted significant improvements in individualized goals, symptom severity, and sleep in studies with low risk of bias. Sensory-based studies (including single subject studies and systematic reviews) reported few positive effects and generally lacked measures of treatment fidelity.

In another review including 25 studies addressing sensory integration therapy for children with ASD, investigators noted positive effects in three studies, mixed findings in eight, and no benefits in 14.^49^ The review considered “sensory integration” broadly, and did not differentiate manualized sensory integration from approaches such as weighted vests or brushing. Investigators considered 16 studies to report a “suggestive” (vs. conclusive) level of evidence based on methodologic limitations and concluded that the evidence base does not support use of sensory integration to treat children with ASD.

One review assessing sensory-based treatment in children with disabilities (including 236 of 856 children with ASD) included 15 comparative studies (including 13 RCTs) and 15 single subject design studies.^6^ Investigators noted methodologic flaws in randomization (for comparative studies) and blinding and fidelity and reported inconsistent results for sensory integration approaches (no group differences in 3 studies, improvements in sensory behaviors and goal attainment in the sensory treatment arm in 4, and greater improvements with behavioral vs. sensory treatment in 2 other studies). Evidence for positive effects of weighted vests was lacking in six studies and mixed results for therapy balls in two studies. Overall the review concluded that inconclusive evidence supports the efficacy of sensory-based approaches and that such approaches are more likely to be ineffective than effective for the majority of children with developmental disabilities.

Another review of single subject studies of individuals with disabilities assessed “sensory integration” broadly and included 17 studies, six including children with ASD.^48^ The investigators considered all studies to have high risk of bias and noted a lack of evidence for the efficacy of interventions: few studies reported positive effects, even those studies with better quality.

A third systematic review also focused on sensory approaches for children with behavioral problems (not necessarily ASD) and included 14 studies (11 included children with ASD, n=185).^10^ Seven studies were single-subject design and four were RCTs. Investigators rated all studies as excellent or good quality on the PEDro scale and categorized interventions as tactile-, proprioceptive-, or vestibular-based. The review noted some positive effects associated with tactile approaches, particularly massage, on challenging behaviors including inattention. Proprioceptive studies—all single subject—evaluated weighted vests and reported mixed findings related to on-task, self-stimulatory, and stereotypic behaviors (improved findings in one study, mixed in two, and no effects in another). Vestibular-based approaches included therapy balls/cushions and horseback riding. Investigators noted limited positive effects on engagement in classroom activities associated with therapy balls. The review concluded that evidence for effectiveness of sensory-based interventions remains unclear.

Two other reviews focused broadly on interventions to improve social participation, play, adaptive behavior, education, and repetitive behavior included few studies addressing sensory challenges (n=3) and noted insufficient evidence for effects on social communication^47^ and positive effects on self-care in one RCT.^46^

#### Other Reviews

Auditory Integration. One Cochrane review of auditory integration approaches for people with ASD included six RCTs with moderate to high risk of bias.^44^ The review reported some improvements in language and challenging behaviors in small studies with disparate outcome measures and limited followup but concluded that interventions overall were ineffective for individuals with ASD.

Music Therapy. Another Cochrane review of 10 studies (n=165 children with ASD), including materials such as theses and study designs including single subject studies, assessed music therapy and reported significant improvements in social interaction within and outside the therapy context and in communication and social reciprocity in the therapy context.^52^ Nonverbal communication in non-therapy contexts was not significantly improved. The review concluded that music therapy may improve social interaction, communication, social reciprocity skills in children with ASD. These results differ from those reported in the current review, likely because we included only comparative studies of music therapy with at least 10 participants.

Massage. One review of massage therapy for children with ASD included six comparative studies and reported some positive effects of massage on symptom severity, communication, and sensory outcomes; however, investigators considered all trials to have high risk of bias.^43^ The review concluded the evidence for massage as an ASD treatment is limited and methodologic limitations do not allow firm conclusions.

## Applicability

Children in studies meeting our review criteria are similar to the general population of children with ASD and associated sensory challenges in that they represent the heterogeneity of impairments and behavioral challenges associated with ASD. Some studies included children with limited functional speech^31, 34^ and/or intellectual disability.^35^, others included children with higher cognitive abilities and milder ASD symptom profiles.^22, 39^ Differences in severity of expression of ASD or in comorbid conditions may limit applicability of findings to children with levels of symptom expression.

Interventions typically used differing approaches incorporating sensory-focused strategies; thus, findings reported here may not be replicated with interventions using different combinations of strategies or targeting different aspects of sensory functioning. Many of the interventions required expertise in specific sensory-related strategies that likely limit their generalizability to community settings; some lacked manualization, and as a consequence likely have limited replicability/community extension. Others were specifically designed to be conducted by parents, under the supervision of a trainer.

In terms of comparison or control interventions, virtually all “control” participants in the included studies were receiving some level of treatment, aside from participants in one RCT.^38^ Some studies attempted to document additional interventions through parent report to demonstrate that baseline rates were comparable across groups, whereas others required that no new interventions be added during the study duration. Outcomes may differ among children receiving different concomitant therapies.

Outcomes also varied across studies, but most studies incorporated commonly used measures of autism symptom severity, behavior, language, and sensory difficulties. Many of these were based upon parent report, although an increasing number used standardized interactive or observational measurement strategies. Some studies also incorporated outcomes of key importance to parents/caregivers that simultaneously attempted to balance assessing comparability between treatment groups with the heterogeneity inherent in ASD.^21, 22^ Use of validated, standardized measures improves potential generalizability of findings by helping to establish a shared understanding of progress and to compare outcomes across different intervention modalities and studies. Standardized measures supplemented with more individualized assessment strategies can also help to improve sensitivity by measuring smaller effects and incorporating elements of children’s individual family or treatment context.

Treatment duration ranged from a week to 10 months, and most studies reported outcomes immediately following the end of treatment, making durability of effects difficult to assess. Few studies attempted to assess characteristics of the child, family, provider, or intervention approach that may affect outcomes, or whether outcomes extended to other settings and environments. However, the use of control groups, treatment fidelity checks, and replicable and manualized intervention protocols establishes a promising baseline for future investigations.

Given the heterogeneity of these studies, and the heterogeneity of children with ASD, the extent of generalizability to the overall population of children with ASD and sensory challenges is limited and difficult to assess.

## Implications for Clinical and Policy Decisionmaking

This review provides limited evidence for decisionmaking about interventions targeting sensory challenges. The small body of comparative literature provides some evidence to support sensory integration-based and touch/massage-based interventions for some children; both interventions positively affected sensory challenges and motor skills. Studies were typically short term and included few children, however, so our confidence in these effects is low.

Decisional dilemmas remain regarding characteristics of the child, family, or intervention that may modify effectiveness or predict which children may be most likely to benefit from a given approach. Similarly, the literature base is currently insufficient to inform our understanding of the time to effect of interventions, longer-term effectiveness of interventions, generalizability of effects outside the treatment context, and components that may drive effectiveness. Though not explicitly assessed in the studies reported here, harms associated with these approaches are likely minimal and caregivers and clinicians must balance the need to ameliorate sensory challenges with the costs of time, effort, and costs and demands of other interventions that a child may receive. As such, caregivers and referring providers should assess the possible benefits of specific sensory-focused intervention modalities based upon the individual needs of the child, broader family goals and capacities, and interventions of more established effectiveness. In this capacity, some practice groups have recommended clear communication regarding the limits of intervention.^53, 54^

## Limitations of the Comparative Effectiveness Review Process

We included studies published in English only and did not include unpublished data or data in theses or conference proceedings. We scanned a random sample of 150 non-English abstracts retrieved by our MEDLINE search. Most studies appeared to be case series, narrative reviews, basic science studies, or studies assessing etiology. Only two studies appeared to meet inclusion criteria; thus, given the high percentage of ineligible items in this scan (99%), we concluded that excluding non-English studies would not introduce significant bias into the review. We recognize that this preliminary scan did not address the entire corpus of ASD literature published in other languages.

We also included only comparative studies of interventions with a sensory-specific focus and including at least 10 children with ASD. This undoubtedly means that most single-subject design studies are not included in this review. Single-subject designs can be helpful in assessing response to treatment in very short timeframes and under very tightly controlled circumstances, but they typically do not provide information on longer-term or functional outcomes. Such studies are useful in demonstrating effects, yielding initial evidence that an intervention merits further study or in identifying whether a particular approach to treatment is likely to be helpful for a specific child. Our goal was to identify and review the best evidence for assessing the effectiveness of interventions targeting sensory challenges in children with ASD, with an eye toward utility in the larger population of children with ASD. By definition, “populations” in single-subject design studies are likely to be idiosyncratic and therefore unlikely to provide information that is generalizable. We also included summaries of other recent reviews to attempt to mitigate any loss of information associated with this criterion.

We also note that other approaches to categorizing sensory-focused interventions could be used and that consensus on a categorization approach is lacking. We chose to group studies based on the core strategies used in each intervention. In some cases this approach functionally grouped interventions that may have used specific, manualized techniques with others that used only a subset of those techniques (e.g., Ayres-based sensory integration and sensory integration models that may have used some Ayres strategies). As noted, no alternative analytic approaches (e.g., considering Ayres-based approaches and other sensory integration approaches as separate categories) would have changed our overall strength of evidence assessment.

This review was also focused specifically on children with ASD and specifically on interventions targeting sensory challenges. Sensory approaches may be used with individuals with other impairments, and findings may be generalizable to children with ASD; however, including studies in children with other conditions was beyond the scope of the current review.

We also recognize that interventions with a primarily educational or behavioral focus may also address sensory-related outcomes, but inclusion of any intervention approach reporting a sensory-related outcome was outside the scope of the current review. Similarly, we focused on child-related outcomes and did not address measures of parent stress, despite the key importance of the outcome and family context. Finally, we used a non-validated tool to assess risk of bias, though we note that the tool evaluates similar constructs to those assessed in tools such as that used by the Cochrane Collaboration, with the addition of ASD-specific domains.

## Limitations of the Evidence Base

As noted, studies in the review had small sample sizes (median 34 total) and typically limited duration of intervention and followup after intervention. Populations across studies were heterogeneous in terms of sensory challenges, ASD severity, age, and intellectual and adaptive functioning. Roughly half of studies (12 of 23) did not control for concomitant interventions or report assessment of treatment fidelity. Few used an appropriate statistical analysis (e.g., correction for multiple testing). Ten of 23 studies did not use blinded outcome assessors.

Interventions, even within our broader categories, used differing sensory-specific approaches in differing combinations of components, settings, and duration. Longer-term outcomes are limited as is our ability to determine effects of intervention on the underlying sensory challenges themselves. Potential harms of interventions were addressed in only one study, and few studies assessed potential factors that may modify effectiveness or drive effects of interventions. Studies often used multicomponent strategies, and teasing apart effects of specific components is not currently possible.

Despite these limitations, investigators have made significant improvements in incorporating commonly used measures of symptom severity, behavior, language, and sensory difficulties to facilitate comparisons across studies. Parent-reported outcomes are necessary in this population of children, many of whom may not be able to complete aspects of assessments; however, studies are increasingly incorporating standardized interactive or observational measurement strategies. As noted above, the increasing use of treatment fidelity measures and replicable intervention protocols establishes a promising baseline for future investigations. Investigators in the area are also well-aware of the challenges of conducting research using a disparate and variously defined set of approaches in a highly heterogeneous population and have made strides in incorporating outcome measures that attempt to balance heterogeneity and comparative effectiveness and measures of intervention fidelity.^15^

## Research Gaps and Areas for Future Research

Improving research in this area should also include considerations of power and sample size. Sample size was frequently insufficient to allow firm conclusions. In addition, researchers should continue to provide adequate detail as they describe their populations and interventions to allow for replicable research. Ideally, investigators publish the treatment manuals they develop, which are then referenced in later research; despite gains in this area, many studies made general references to their use of an underlying approach without specifying the ways in which they used or modified the technique. Lack of detail about the intervention makes it difficult to assess the applicability of individual studies, to synthesize groups of studies, or to replicate studies.

Duration of treatment and followup were generally short, and the extent to which effects of therapies could be expected to continue after cessation of treatment is not clear. While some approaches may not hypothesize such durability (i.e., approaches designed for ongoing use with improvements associated with continued treatment), such data are ultimately necessary for guiding pragmatic implementation and setting realistic expectations of effects for clinicians and families.

In addition, few studies adequately accounted for concomitant interventions that might confound observed effectiveness. Accounting for concomitant interventions should be standardized in future research.

As noted, more studies used a common set of outcome measures, but the extent to which these measures assess changes in potential underlying sensory-related impairments is not clear, and understanding whether intervention can alter potential impairments in sensory processing (vs. altering behavioral responses in the short term) is a critical need. Translational work to understand the relationship between sensory symptoms and their potential neurobiology would inform intervention design.

Another critical area for further research is identifying which children are likely to benefit from particular interventions. To date, studies have provided limited characterization of the subpopulation of children who experience positive response to intervention and limited characterization of the extent or type of sensory challenges children experience at baseline. Interventions targeting sensory challenges by their nature often employ multiple components, and data on whether specific functional components of the interventions drive effectiveness are currently unavailable. Component analyses in this field would be productive for refining intervention approaches and for assessing applicability and generalizability of the results.

In line with this need, we recommend future consideration of the ways in which the cultural context of the child and family may affect the applicability or effectiveness of specific interventions. The setting of interventions may also influence effects, and understanding the role of context broadly in contributing to effects is an important need. As noted, understanding the extent to which findings from studies of these interventions in children with other conditions are applicable to children with ASD may help to bolster the evidence base.

## Conclusions

Some interventions targeting sensory challenges may lead to modest improvements primarily in sensory- and ASD symptom severity-related outcomes; however, the evidence base for any category of intervention is small, and durability of effects beyond the immediate intervention period is unclear. Sensory integration-based approaches improved outcomes related to sensory challenges and motor skills, and studies of massage reported improvements in sensory responses and ASD symptoms. Environmental enrichment was also associated with improvements in nonverbal cognitive skills in the short-term. Auditory integration-based approaches did not improve language outcomes. Some positive effects were associated with other approaches studied (music therapy, weighted blankets) but findings in these small studies were not consistent. Data on longer-term results are lacking, as are data on characteristics that modify outcomes, generalizability of findings, and components of interventions that may drive effects. In sum, while some therapies may hold promise and warrant further study, substantial needs exist for continuing improvements in methodologic rigor in the field.