# Appendix G Detailed Table of Findings

Table G-1 Key findings in studies of interventions targeting sensory challenges

## References

1 Iwanaga R, Honda S, Nakane H, . Pilot study: efficacy of sensory integration therapy for Japanese children with high-functioning autism spectrum disorder. Occup Ther Int 2014 Mar;21(1):4–11.23893373
2 Schaaf RC, Benevides T, Mailloux Z, . An intervention for sensory difficulties in children with autism: a randomized trial. J Autism Dev Disord 2014 Jul;44(7):1493–506.24214165
3 Pfeiffer BA, Koenig K, Kinnealey M, . Effectiveness of sensory integration interventions in children with autism spectrum disorders: a pilot study. Am J Occup Ther 2011 Jan–Feb;65(1):76–85.21309374
4 Fazlioglu Y, Baran G. A sensory integration therapy program on sensory problems for children with autism. Percept Mot Skills 2008 Apr;106(2):415–22.18556898
5 Woo CC, Leon M. Environmental enrichment as an effective treatment for autism: a randomized controlled trial. Behav Neurosci 2013 Aug;127(4):487–97.23688137
6 Woo CC, Donnelly JH, Steinberg-Epstein R, . Environmental enrichment as a therapy for autism: A clinical trial replication and extension. Behav Neurosci 2015 Aug;129(4):412–22.26052790
7 Mudford OC, Cross BA, Breen S, . Auditory integration training for children with autism: no behavioral benefits detected. Am J Ment Retard 2000 Mar;105(2):118–29.10755175
8 Corbett BA, Shickman K, Ferrer E. Brief report: the effects of Tomatis sound therapy on language in children with autism. J Autism Dev Disord 2008 Mar;38(3):562–6.17610057
9 Porges SW, Bazhenova OV, Bal E, . Reducing auditory hypersensitivities in autistic spectrum disorder: preliminary findings evaluating the listening project protocol. Front Pediatr 2014;2:80.25136545
10 Srinivasan SM, Eigsti I-M, Gifford T, . The effects of embodied rhythm and robotic interventions on the spontaneous and responsive verbal communication skills of children with Autism Spectrum Disorder (ASD): A further outcome of a pilot randomized controlled trial. Research in Autism Spectrum Disorders 2016;27:73–87.27668011
11 Srinivasan SM, Eigsti IM, Neelly L, . The effects of embodied rhythm and robotic interventions on the spontaneous and responsive social attention patterns of children with Autism Spectrum Disorder (ASD): A pilot randomized controlled trial. Res Autism Spectr Disord 2016 Jul;27:54–72.27453721
12 Ghasemtabar SN, Hosseini M, Fayyaz I, . Music therapy: An effective approach in improving social skills of children with autism. Adv Biomed Res 2015;4:157.26380242
13 Thompson GA, McFerran KS, Gold C. Family-centred music therapy to promote social engagement in young children with severe autism spectrum disorder: a randomized controlled study. Child Care Health Dev 2014 Nov;40(6):840–52.24261547
14 Gattino GS, dos Santos Riesgo R, Longo D, . Effects of relational music therapy on communication of children with autism: A randomized controlled study. Nordisk tidskrift for musikkterapi - Nordic Journal of Music Therapy 2011 2015-12-09;20(2):142–54; 2011-14788-003.
15 Kim J, Wigram T, Gold C. The effects of improvisational music therapy on joint attention behaviors in autistic children: a randomized controlled study. J Autism Dev Disord 2008 Oct;38(9):1758–66.18592368
16 Silva LM, Schalock M, Gabrielsen KR, . Early Intervention with a Parent-Delivered Massage Protocol Directed at Tactile Abnormalities Decreases Severity of Autism and Improves Child-to-Parent Interactions: A Replication Study. Autism Res Treat 2015;2015:904585.25878901
17 Silva L, Schalock M. Treatment of tactile impairment in young children with autism: results with qigong massage. Int J Ther Massage Bodywork 2013;6(4):12–20.24298297
18 Silva LM, Schalock M, Gabrielsen K. Early intervention for autism with a parent-delivered Qigong massage program: a randomized controlled trial. Am J Occup Ther 2011 Sep–Oct;65(5):550–9.22026323
19 Piravej K, Tangtrongchitr P, Chandarasiri P, . Effects of Thai traditional massage on autistic children’s behavior. J Altern Complement Med 2009 Dec;15(12):1355–61.20001837
20 Silva LM, Schalock M, Ayres R, . Qigong massage treatment for sensory and self-regulation problems in young children with autism: a randomized controlled trial. Am J Occup Ther 2009 Jul–Aug;63(4):423–32.19708471
21 Lee HK. Effects of Massage and Attachment Promotion Program on Social Maturity, Child Autism and Attachment of Children with Autism and Their Mothers. J Korean Acad Child Health Nurs 2008 1;14(1):14–21.
22 Silva LM, Cignolini A, Warren R, . Improvement in sensory impairment and social interaction in young children with autism following treatment with an original Qigong massage methodology. Am J Chin Med 2007;35(3):393–406.17597498
23 Latham SO, Stockman IJ. Effect of augmented sensorimotor input on learning verbal and nonverbal tasks among children with autism spectrum disorders. J Autism Dev Disord 2014 Jun;44(6):1288–302.24234676
24 Gringras P, Green D, Wright B, . Weighted blankets and sleep in autistic children--a randomized controlled trial. Pediatrics 2014 Aug;134(2):298–306.25022743