# Appendix F Applicability of Findings

Table F-1 Applicability of evidence for sensory integration

Domain | Description of applicability of evidence
Population | Studies included children ages 2 up to 12 years and vast majority were males (80% or higher in all studies). Most studies included children with difficulty processing and integrating sensory information. Mean IQ was reported in three studies with values ranging from 90 to 110. The fourth study recruited children aged 7 to 11 from a special education program the majority of whom were non-verbal. Participants were often receiving concomitant behavioral and or pharmacological treatments.
Intervention | Sensory integration.
Comparators | Comparators included fine motor intervention, group therapy and usual care.
Outcomes | Outcomes included sensory problems, cognition, verbal, motor, speech, and behavior. Assessment using Japanese version of MAP, Goal Attainment Scaling, Pediatric Evaluation of Disability Inventory, PDDBI, VABS, Sensory Evaluation for Children, Sensory Processing Measure, and Social Responsiveness Scale. Treatment duration ranged from 6 weeks up to 10 months with no long-term follow-up.
Setting | Two studies were conducted in the United States and one each in Japan and Turkey.

PDDBI = Pervasive Developmental Disorders Behavior Inventory; VABS = Vineland Adaptive Behavior Scale; MAP = Miller Assessment for Preschoolers

Table F-2 Applicability of evidence for environmental enrichment

Domain | Description of applicability of evidence
Population | Participants ranged in age from 3 to 12 years old and were exclusively male in one study. The second study restricted to ages 3 to 6 and included a small number of female participants (14%). Most were receiving concomitant behavior therapies. Autism diagnosis was confirmed by ADOS scoring in both studies.
Intervention | Sensorimotor enrichment-daily exposure to multiple sensori motor stimuli.
Comparators | The comparator for both studies was standard care.
Outcomes | Outcomes included change in autism severity measured by CARS and ADOS and cognition determined by Leiter-R Visualization and Reasoning scores. Sensory reactivity was assessed using the Short Sensory Profile. Interventions were 6 months duration in both studies.
Setting | Both studies were conducted at the same academic medical center in the United States.

ADOS = Autism Diagnostic Observation Scale; CARS = Childhood Autism Rating Scale

Table F-3 Applicability of evidence for auditory integration

Domain | Description of applicability of evidence
Population | Children ranged from ages 3–13 years. All participants had a diagnosis of autism and were low-functioning, having significant cognitive and/or language delays.
Intervention | Auditory integration using the Tomatis method or a more generalized training protocol.
Comparators | Both studies used a crossover design comparing auditory integration to placebo within individual subjects.
Outcomes | Outcomes included behavior, cognitive and language skills obtained from direct observation and parent reports. Assessment tools used included VABS, Reynell Language Development Scales, Leiter International Performance Scale, ADOS, Stanford-Binet Intelligence Scale, Peabody Picture Vocabulary test, and Expressive One Word Vocabulary test. Both interventions were less than 1 month duration.
Setting | One study was conducted in the United States and one in the United Kingdom.

ADOS = Autism Diagnostic Observation Scale; VABS = Vineland Adaptive Behavior Scale

Table F-4 Applicability of evidence for music therapy

Domain | Description of applicability of evidence
Population | Most studies were conducted in preschool aged children except for two studies that included children up to age 12. The severity of ASD varied widely with some studies including mild to moderate ASD and others including children with severe ASD based on CARS scores and including verbal and non-verbal participants.
Intervention | Music therapy, filtered music.
Comparators | Comparators included unfiltered music, headphone control, toy play, robotic interventions, tabletop activities, and no intervention
Outcomes | Outcomes included social engagement, social skills, speech and language, joint attention and non-verbal social communication, and hearing sensitivity. The instruments used to assess changes included VSEEC, SSRS, PDDBI, ESCS, measures of joint attention, and parent questionnaires on hearing sensitivity. Interventions were of short duration ranging from 1 up to 16 weeks with no long-term follow-up. One Iranian study in school-aged children assessed social skills two months after intervention.
Setting | Studies were conducted in the United States, Brazil, Australia, Korea and Iran.

CARS = Childhood Autism Rating Scale; VSEEC = Vineland Social-Emotional Early Childhood ; SSRS = Social Skills Rating System; PDDBI = Pervasive Developmental Disorders Behavior Inventory; ESCS = Early Social Communication Scales

Table F-5 Applicability of evidence for massage/touch therapy

Domain | Description of applicability of evidence
Population | Participants ranged in age from 3 to 16 years across studies. Majority of study participants were male. The severity of ASD including degree of intellectual disability was not well characterized.
Intervention | Qigong sensory massage, other massage
Comparators | Comparators were observation or waitlist controls and massage plus sensory intervention and attachment therapy alone.
Outcomes | Outcomes included sensory impairment, adaptive behavior, autistic behavior, language skills, social abilities, and bowel and sleep abnormalities. Measurement instruments included Sensory Profile, ABC, VABS, PDDBI, and parent questionnaires to describe bowel and sleep patterns. The massage studies were of 4–5 months duration.
Setting | Studies were conducted in the United States and Korea

ABC = Autism Behavior Checklist; VABS = Vineland Adaptive Behavior Scale; PDDBI = Pervasive Developmental Disorders Behavior Inventory