# Appendix D Excluded Studies

Reasons for Exclusion

X-1 | Does not address interventions or outcomes of interest
X-2 | Not original research
X-3 | Does not include an appropriate comparison group
X-4 | Does not meet sample size criterion
X-5 | Not in English or not obtainable

1 Finucane BM, Lusk L, Arkilo D, . 15q Duplication Syndrome and Related Disorders. In: Pagon RA, Adam MP, Ardinger HH, Wallace SE, Amemiya A, Bean LJH, , eds. GeneReviews(R). Seattle (WA): University of Washington, Seattle University of Washington, Seattle. All rights reserved.; 1993.
2 Humphries TW, Snider L, McDougall B. Clinical evaluation of the effectiveness of sensory integrative and perceptual motor therapy in improving sensory integrative function in children with learning disabilities. Occupational Therapy Journal of Research. 1993 2015-04-15;13(3):163–82; 1994-03315-001. X-1
3 Mefford H, Mitchell E, Hodge J. 17q12 Recurrent Duplication. In: Pagon RA, Adam MP, Ardinger HH, Wallace SE, Amemiya A, Bean LJH, , eds. GeneReviews(R). Seattle (WA): University of Washington, Seattle University of Washington, Seattle. All rights reserved.; 1993.
4 Morgan A, Fisher SE, Scheffer I, . FOXP2-Related Speech and Language Disorders. In: Pagon RA, Adam MP, Ardinger HH, Wallace SE, Amemiya A, Bean LJH, , eds. GeneReviews(R). Seattle (WA): University of Washington, Seattle University of Washington, Seattle. All rights reserved.; 1993.
5 Van Dijck A, Helsmoortel C, Vandeweyer G, . ADNP-Related Intellectual Disability and Autism Spectrum Disorder. In: Pagon RA, Adam MP, Ardinger HH, Wallace SE, Amemiya A, Bean LJH, , eds. GeneReviews(R). Seattle (WA): University of Washington, Seattle University of Washington, Seattle. All rights reserved.; 1993.
6 Buday EM. The effects of signed and spoken words taught with music on sign and speech imitation by children with autism. Journal of Music Therapy. 1995 2016-04-29;32(3):189–202. doi: http://dx.doi.org/10.1093/jmt/32.3.189; 1996-14715-001. X-3, X-4
7 Davidson T, Williams B. Occupational therapy for children with developmental coordination disorder: A study of the effectiveness of a combined sensory integration and perceptual-motor intervention. The British Journal of Occupational Therapy. 2000 2016-05-11;63(10):495–9. doi: http://dx.doi.org/10.1177/030802260006301007; 2000-16436-006. X-1
8 Niederhofer H. Venlafaxine has modest effects in autistic children. Therapy 2004. 2004/09/01;1(1):87–90. doi: 10.2217/14750708.1.1.87. X-1
9 Seltzer MM, Shattuck P, Abbeduto L, . Trajectory of development in adolescents and adults with autism. Ment Retard Dev Disabil Res Rev. 2004;10(4):234–47. doi: 10.1002/mrdd.20038. X-415666341
10 AHRQ Comparative Effectiveness ReviewsTherapies for Children With Autism Spectrum Disorder: A Review of the Research for Parents and Caregivers. Comparative Effectiveness Review Summary Guides for Consumers. Rockville (MD): Agency for Healthcare Research and Quality (US); 2005. X-1
11 AHRQ Comparative Effectiveness Reviews Therapies for Children With Autism Spectrum Disorders: A Review of the Research for Parents and Caregivers. Comparative Effectiveness Review Summary Guides for Consumers. Rockville (MD): Agency for Healthcare Research and Quality (US); 2005. X-1
12 Solomons S. Using aromatherapy massage to increase shared attention behaviours in children with autistic spectrum disorders and severe learning difficulties. British Journal of Special Education. 2005;32(3):127–37. doi: 10.1111/j.0952-3383.2005.00385.x. X-1, X-3, X-4
13 Arnold LE, Aman MG, Cook AM, . Atomoxetine for hyperactivity in autism spectrum disorders: placebo-controlled crossover pilot trial. J Am Acad Child Adolesc Psychiatry. 2006 Oct;45(10):1196–205. doi: 10.1097/01.chi.0000231976.28719.2a [doi] 00004583-200610000-00007 [pii].17003665
14 Williams TI. Evaluating effects of aromatherapy massage on sleep in children with autism: a pilot study. Evid Based Complement Alternat Med. 2006 Sep;3(3):373–7. doi: 10.1093/ecam/nel017. X-1, X-316951722
15 Boso M, Emanuele E, Minazzi V, . Effect of long-term interactive music therapy on behavior profile and musical skills in young adults with severe autism. J Altern Complement Med. 2007 Sep;13(7):709–12. doi: 10.1089/acm.2006.6334. X-117931062
16 Hilton C, Graver K, LaVesser P. Relationship between social competence and sensory processing in children with high functioning autism spectrum disorders. Research in Autism Spectrum Disorders. 2007 2015-12-09;1(2):164–73. doi: http://dx.doi.org/10.1016/j.rasd.2006.10.002; 2007-12217-004. X-1
17 AHRQ Comparative Effectiveness Reviews Comparative Effectiveness of Therapies for Children With Autism Spectrum Disorder. Comparative Effectiveness Review Summary Guides for Clinicians. Rockville (MD): Agency for Healthcare Research and Quality (US); 2007. X-1
18 Comparative Effectiveness Reviews Comparative Effectiveness of Therapies for Children With Autism Spectrum Disorders. Comparative Effectiveness Review Summary Guides for Clinicians. Rockville (MD): Agency for Healthcare Research and Quality (US); 2007. X-1
19 Kern P, Wolery M, Aldridge D. Use of songs to promote independence in morning greeting routines for young children with autism. J Autism Dev Disord. 2007 Aug;37(7):1264–71. doi: 10.1007/s10803-006-0272-1. X-117120150
20 McNally P, McNicholas F, Oslizlok P. The QT interval and psychotropic medications in children: recommendations for clinicians. Eur Child Adolesc Psychiatry. 2007 Feb;16(1):33–47. doi: 10.1007/s00787-006-0573-0. X-116944043
21 Myers SM, Johnson CP. Management of children with autism spectrum disorders. Pediatrics. 2007 Nov;120(5):1162–82. doi: peds.2007-2362 [pii] 10.1542/peds.2007-2362 [doi]. X-1 X-2 X-3 X-4 REFERENCES17967921
22 Watling RL, Dietz J. Immediate effect of Ayres’s sensory integration-based occupational therapy intervention on children with autism spectrum disorders. Am J Occup Ther. 2007 Sep–Oct;61(5):574–83. X-3, X-417944295
23 Woodard C, Groden J, Goodwin M, . A placebo double-blind pilot study of dextromethorphan for problematic behaviors in children with autism. Autism. 2007 Jan;11(1):29–41. doi: 10.1177/1362361307070989. X-1, X-417175572
24 Chungpaibulpatana J, Sumpatanarax T, Thadakul N, . Hyperbaric oxygen therapy in Thai autistic children. J Med Assoc Thai. 2008 Aug;91(8):1232–8. X-3, X-418788696
25 Clark DL, Arnold LE, Crowl L, . Vestibular Stimulation for ADHD: randomized controlled trial of Comprehensive Motion Apparatus. J Atten Disord. 2008 Mar;11(5):599–611. doi: 10.1177/1087054707311042. X-118198165
26 Ospina MB, Krebs Seida J, Clark B, . Behavioural and developmental interventions for autism spectrum disorder: a clinical systematic review. PLoS One. 2008;3(11):e3755. doi: 10.1371/journal.pone.0003755 [doi]. X-219015734
27 Petrus C, Adamson SR, Block L, . Effects of exercise interventions on stereotypic behaviours in children with autism spectrum disorder. Physiother Can. 2008 Spring;60(2):134–45. doi: 10.3138/physio.60.2.134. X-2, X-320145777
28 Rodger S, Ireland S, Vun M. Can Cognitive Orientation to daily Occupational Performance (CO-OP) help Children with Asperger’s Syndrome to Master Social and Organisational Goals? The British Journal of Occupational Therapy. 2008 January 1, 2008;71(1):23–32. doi: 10.1177/030802260807100105. X-1, X-2, X-3
29 Silva LM, Ayres R, Schalock M. Outcomes of a pilot training program in a qigong massage intervention for young children with autism. Am J Occup Ther. 2008 Sep–Oct;62(5):538–46. X-318826014
30 Correll CU, Manu P, Olshanskiy V, . Cardiometabolic risk of second-generation antipsychotic medications during first-time use in children and adolescents. Jama. 2009 Oct 28;302(16):1765–73. doi: 10.1001/jama.2009.1549. X-119861668
31 Cox AL, Gast DL, Luscre D, . The effects of weighted vests on appropriate in-seat behaviors of elementary-age students with autism and severe to profound intellectual disabilities. Focus on Autism and Other Developmental Disabilities. 2009 2015-12-09;24(1):17–26. doi: http://dx.doi.org/10.1177/1088357608330753; 2009-02961-002. X-3, X-4
32 Keino H, Funahashi A, Keino H, . Psycho-educational Horseback Riding to Facilitate Communication Ability of Children with Pervasive Developmental Disorders. J Equine Sci. 2009;20(4):79–88. doi: 10.1294/jes.20.79. X-1, X-324833971
33 Kim J, Wigram T, Gold C. Emotional, motivational and interpersonal responsiveness of children with autism in improvisational music therapy. Autism. 2009 Jul;13(4):389–409. doi: 10.1177/1362361309105660. X-1, X-419535468
34 Lundqvist L-O, Andersson G, Viding J. Effects of vibroacoustic music on challenging behaviors in individuals with Autism and developmental disabilities. Research in Autism Spectrum Disorders. 2009 2015-12-09;3(2):390–400. doi: http://dx.doi.org/10.1016/j.rasd.2008.08.005; 2010-06021-009. X-1
35 Seida JK, Ospina MB, Karkhaneh M, . Systematic reviews of psychosocial interventions for autism: an umbrella review. Dev Med Child Neurol. 2009 Feb;51(2):95–104. doi: DMCN3211 [pii] 10.1111/j.1469-8749.2008.03211.x [doi]. X-219191842
36 Stephenson J, Carter M. The use of weighted vests with children with autism spectrum disorders and other disabilities. J Autism Dev Disord. 2009 Jan;39(1):105–14. doi: 10.1007/s10803-008-0605-3. X-218592366
37 Van Rie GL, Heflin LJ. The effect of sensory activities on correct responding for children with autism spectrum disorders. Research in Autism Spectrum Disorders. 2009 2015-12-09;3(3):783–96. doi: http://dx.doi.org/10.1016/j.rasd.2009.03.001; 2010-06022-019. X-1, X-3, X-4
38 Autism spectrum disorders. Diagnosis and management involve time and patience. Harv Ment Health Lett. 2010 Sep;27(3):4–5. X-1
39 Autism spectrum disorders and the gut. Consensus recommendations for evaluation and treatment. Harv Ment Health Lett. 2010 Apr;26(10):4. X-1, X-2, X-3
40 Massachusetts & New Hampshire. Insurance; autism spectrum disorders. Ment Phys Disabil Law Rep. 2010 Sep–Oct;34(5):812. X-1
41 Current world literature. Curr Opin Neurol. 2010 Apr;23(2):194–201. doi: 10.1097/WCO.0b013e328338cade. X-1, X-220216346
42 Mental health. Nursing Times. 2010;106(31):7- 1p. Language: English. Entry Date: 20101001. Revision Date: 20150711. Publication Type: Journal Article. X-1, X-2
43 Medication plus behavioral intervention for aggression in autism. Brown University Child & Adolescent Psychopharmacology Update. 2010;12(8):4–5 2p. Language: English. Entry Date: 20101001. Revision Date: 20150711. Publication Type: Journal Article. Journal Subset: Biomedical. X-1, X-2, X-3
44 FDA warns maker of product used as alternative autism treatment. Contemporary Rehab. 2010;66(4):7- 1p. Language: English. Entry Date: 20101126. Revision Date: 20150711. Publication Type: Journal Article. X-1, X-2
45 Lack of evidence for antidepressant use in autism. Contemporary Rehab. 2010;66(4):11- 1p. Language: English. Entry Date: 20101126. Revision Date: 20150711. Publication Type: Journal Article. X-1, X-2
46 Divalproex sodium for irritability in autism. Brown University Child & Adolescent Psychopharmacology Update. 2010;12(7):7- 1p. Language: English. Entry Date: 20100827. Revision Date: 20150711. Publication Type: Journal Article. X-1, X-2
47 NAC effective for self-injurious behavior in 4-year-old with ASD. Brown University Child & Adolescent Psychopharmacology Update. 2010;12(5):7–8 2p. Language: English. Entry Date: 20150227. Revision Date: 20150710. Publication Type: Journal Article. Journal Subset: Biomedical. X-1, X-2, X-3, X-4
48 Clozapine for aggression in adolescent autism. Brown University Child & Adolescent Psychopharmacology Update. 2010;12(5):8- 1p. Language: English. Entry Date: 20150227. Revision Date: 20150711. Publication Type: Journal Article. X-1, X-2
49 Drug & device news. Medical Malpractice Law & Strategy. 2010;27(8):5- 1p. Language: English. Entry Date: 20100709. Revision Date: 20150711. Publication Type: Journal Article. Journal Subset: Biomedical. X-1, X-2
50 Keep your eye on. Brown University Child & Adolescent Behavior Letter. 2010;26(4):2- 1p. Language: English. Entry Date: 20100507. Revision Date: 20150711. Publication Type: Journal Article. Journal Subset: Biomedical. X-1, X-2
51 Oxytocin improves social interaction in autistic patients. Brown University Child & Adolescent Psychopharmacology Update. 2010;12(4):7–8 2p. Language: English. Entry Date: 20100521. Revision Date: 20150711. Publication Type: Journal Article. Journal Subset: Biomedical. X-1, X-2
52 Briefly noted. Mental Health Weekly. 2010;20(7):7–8 2p. Language: English. Entry Date: 20100402. Revision Date: 20150711. Publication Type: Journal Article. X-1, X-2
53 Aripiprazole effective in treating irritability in autistic youth. Brown University Child & Adolescent Psychopharmacology Update. 2010;12(2):4–5 2p. Language: English. Entry Date: 20100312. Revision Date: 20150711. Publication Type: Journal Article. Journal Subset: Biomedical. X-2, X-6
54 For the record. Journal of Reproductive Medicine. 2010;55(1–2):2A-A 1p. Language: English. Entry Date: 20100409. Revision Date: 20150711. Publication Type: Journal Article. X-1, X-2
55 Extending trust. Nature Neuroscience. 2010 August;13(8):905. doi: http://dx.doi.org/10.1038/nn0810-905. X-120661262
56 Abdala APL, Dutschmann M, Bissonnette JM, . Correction of respiratory disorders in a mouse model of Rett syndrome. Proceedings of the National Academy of Sciences of the United States of America. 2010 19 Oct;107(42):18208–13. doi: http://dx.doi.org/10.1073/pnas.1012104107. X-120921395
57 Abraham E, Shah S, Parray T. Combination of oral clonidine and midazolam as premedication when ketamine is not an option in an uncooperative autistic patient. Internet Journal of Anesthesiology. 2010;24(1):8p-p 1p. Language: English. Entry Date: 20100820. Revision Date: 20150820. Publication Type: Journal Article. X-1
58 Acef S, Aubrun P. [Somatic care and autism: removal of barriers to reducing inequalities]. Sante Publique. 2010 Sep–Oct;22(5):529–39. X-121360862
59 Agam Y, Joseph RM, Barton JJ, . Reduced cognitive control of response inhibition by the anterior cingulate cortex in autism spectrum disorders. Neuroimage. 2010 Aug 1;52(1):336–47. doi: 10.1016/j.neuroimage.2010.04.010. X-120394829
60 Ahearn WH. What Every Behavior Analyst Should Know About the “MMR Causes Autism” Hypothesis. Behav Anal Pract. 2010 Spring;3(1):46–50. X-122479671
61 Akhondzadeh S. Adjunctive pentoxifylline for disruptive symptoms in autistic children. Brown University Child & Adolescent Psychopharmacology Update. 2010;12(1):4–5 2p. Language: English. Entry Date: 20100212. Revision Date: 20150711. Publication Type: Journal Article. Journal Subset: Biomedical. X-2
62 Akins RS, Angkustsiri K, Hansen RL. Complementary and alternative medicine in autism: An evidence-based approach to negotiating safe and efficacious interventions with families. Neurotherapeutics. 2010 July;7(3):307–19. doi: http://dx.doi.org/10.1016/j.nurt.2010.05.002. X-2, X-320643384
63 Al Anbar NN, Dardennes RM, Prado-Netto A, . Treatment choices in autism spectrum disorder: the role of parental illness perceptions. Res Dev Disabil. 2010 May–Jun;31(3):817–28. doi: 10.1016/j.ridd.2010.02.007. X-120299185
64 Alvarez A. Levels of analytic work and levels of pathology: the work of calibration. Int J Psychoanal. 2010 Aug;91(4):859–78. doi: 10.1111/j.1745-8315.2010.00284.x. X-120840643
65 Aman MG, Arnold LE, Lecavalier L, . Dr. Aman, et al. reply. Journal of the American Academy of Child and Adolescent Psychiatry. 2010 April;49(4):407–8. doi: http://dx.doi.org/10.1097/00004583-201004000-00016. X-1
66 Aman MG, Kasper W, Manos G, . Line-item analysis of the Aberrant Behavior Checklist: results from two studies of aripiprazole in the treatment of irritability associated with autistic disorder. J Child Adolesc Psychopharmacol. 2010 Oct;20(5):415–22. doi: 10.1089/cap.2009.0120.20973712
67 Aman MG, McDougle CJ, Scahill L. Lower dose risperidone combined with parent training improves PDD outcomes…pervasive developmental disorder. Brown University Child & Adolescent Psychopharmacology Update. 2010;12(1):1–3 p. Language: English. Entry Date: 20100212. Revision Date: 20150711. Publication Type: Journal Article. Journal Subset: Biomedical. X-1, X-2
68 Amiet C, Gourfinkel-An I, Consoli A, . [Epilepsy and autism: a complex issue]. Arch Pediatr. 2010 Jun;17(6):650–1. doi: 10.1016/s0929-693x(10)70043-9. X-2, X-320654825
69 Andari E, Duhamel JR, Zalla T, . Promoting social behavior with oxytocin in high-functioning autism spectrum disorders. Proc Natl Acad Sci U S A. 2010 Mar 2;107(9):4389–94. doi: 10.1073/pnas.0910249107. X-1, X-420160081
70 Arieff Z, Kaur M, Gameeldien H, . 5-HTTLPR polymorphism: analysis in South African autistic individuals. Hum Biol. 2010 Jun;82(3):291–300. doi: 10.3378/027.082.0303. X-120649385
71 Arnold LE, Farmer C, Kraemer HC, . Moderators, mediators, and other predictors of risperidone response in children with autistic disorder and irritability. J Child Adolesc Psychopharmacol. 2010 Apr;20(2):83–93. doi: 10.1089/cap.2009.0022.20415603
72 Arunkumar T, Supe SS, Ravikumar M, . Electron beam characteristics at extended source-to-surface distances for irregular cut-outs. J Med Phys. 2010 Oct;35(4):207–14. doi: 10.4103/0971-6203.71763. X-121170185
73 Assouline B. [Autism announcement at consultation is a therapeutic step]. Arch Pediatr. 2010 Jun;17(6):647–8. doi: 10.1016/s0929-693x(10)70041-5. X-520654823
74 Athens ES, Vollmer TR. An investigation of differential reinforcement of alternative behavior without extinction. J Appl Behav Anal. 2010 Winter;43(4):569–89. doi: 10.1901/jaba.2010.43-569. X-1, X-321541145
75 Atladottir HO, Thorsen P, Ostergaard L, . Maternal infection requiring hospitalization during pregnancy and autism spectrum disorders. J Autism Dev Disord. 2010 Dec;40(12):1423–30. doi: 10.1007/s10803-010-1006-y. X-120414802
76 Atladottir HO, Thorsen P, Schendel DE, . Association of hospitalization for infection in childhood with diagnosis of autism spectrum disorders: a Danish cohort study. Arch Pediatr Adolesc Med. 2010 May;164(5):470–7. doi: 10.1001/archpediatrics.2010.9. X-120439799
77 Auyeung B, Taylor K, Hackett G, . Foetal testosterone and autistic traits in 18 to 24-month-old children. Mol Autism. 2010;1(1):11. doi: 10.1186/2040-2392-1-11. X-120678186
78 Axe JB, Sainato DM. Matrix training of preliteracy skills with preschoolers with autism. J Appl Behav Anal. 2010 Winter;43(4):635–52. doi: 10.1901/jaba.2010.43-635. X-1, X-3, X-421541149
79 Bagatell N, Mirigliani G, Patterson C, . Effectiveness of therapy ball chairs on classroom participation in children with autism spectrum disorders. Am J Occup Ther. 2010 Nov–Dec;64(6):895–903. X-3, X-421218680
80 Baharav E, Reiser C. Using telepractice in parent training in early autism. Telemed J E Health. 2010 Jul–Aug;16(6):727–31. doi: 10.1089/tmj.2010.0029. X-3, X-420583950
81 Baker N. Exploring the mental health nurse practitioner scope of practice in youth early psychosis: an anecdotal account. Contemp Nurse. 2010 Feb–Mar;34(2):211–20. doi: 10.5172/conu.2010.34.2.211. X-1, X-220509805
82 Bakhtiari M, Malhotra H, Jones MD, . Applying graphics processor units to Monte Carlo dose calculation in radiation therapy. J Med Phys. 2010 Apr;35(2):120–2. doi: 10.4103/0971-6203.62198. X-120589122
83 Banda DR, Copple KS, Koul RK, . Video modelling interventions to teach spontaneous requesting using AAC devices to individuals with autism: a preliminary investigation. Disabil Rehabil. 2010;32(16):1364–72. doi: 10.3109/09638280903551525. X-120465397
84 Barba L. A one-stop shop for autism services. Behav Healthc. 2010 Jun;30(6):28, 30–1. X-1
85 Baruth JM, Casanova MF, El-Baz A, . Low-Frequency Repetitive Transcranial Magnetic Stimulation (rTMS) Modulates Evoked-Gamma Frequency Oscillations in Autism Spectrum Disorder (ASD). J Neurother. 2010 Jul 1;14(3):179–94. doi: 10.1080/10874208.2010.501500. X-121116441
86 Baruth JM, Casanova MF, Sears L, . Early-stage visual processing abnormalities in high-functioning autism spectrum disorder (ASD). Transl Neurosci. 2010 Jun;1(2):177–87. doi: 10.2478/v10134-010-0024-9. X-122563527
87 Bathla M, Chandna S, Bathla JC. Rett’s syndrome: Diagnostic and therapeutic dilemma. German Journal of Psychiatry. 2010;13(3):157–60. X-1
88 Bennett M, Mitchell S, Neuman T, . Hyperbaric oxygen therapy and neurological disease. Undersea & hyperbaric medicine : journal of the Undersea and Hyperbaric Medical Society, Inc. 2010 2010;37(5):371–3; author reply 3–4. X-5
89 Bent S, Hendren RL. Improving the prediction of response to therapy in autism. Neurotherapeutics. 2010 July;7(3):232–40. doi: http://dx.doi.org/10.1016/j.nurt.2010.05.011. X-120643375
90 Bertoglio K, Jill James S, Deprey L, . Pilot study of the effect of methyl B12 treatment on behavioral and biomarker measures in children with autism. J Altern Complement Med. 2010 May;16(5):555–60. doi: 10.1089/acm.2009.0177.20804367
91 Bhatara A, Quintin EM, Levy B, . Perception of emotion in musical performance in adolescents with autism spectrum disorders. Autism Res. 2010 Oct;3(5):214–25. doi: 10.1002/aur.147. X-120717952
92 Biemans B, Aubert L, Jagasia R, . The effects of prenatal valproic acid on adult neurogenesis in a mouse model for autism. Behavioural Pharmacology. 2010 September;21 (5–6):587. doi: http://dx.doi.org/10.1097/FBP.0b013e32833dbe35. X-1
93 Bigham S, Boucher J, Mayes A, . Assessing recollection and familiarity in autistic spectrum disorders: methods and findings. Journal of Autism & Developmental Disorders. 2010;40(7):878–89 12p. doi: 10.1007/s10803-010-0937-7. Language: English. Entry Date: 20100820. Revision Date: 20150711. Publication Type: Journal Article. X-120091339
94 Blake KE. Spectrum disorders: a new generation of complex patients. Pa Nurse. 2010 Dec;65(4):9–11, 5. X-5
95 Blankenship K, Erickson CA, Stigler KA, . Aripiprazole for irritability associated with autistic disorder in children and adolescents aged 6–17 years. Ped Health. 2010 Sep 29;4(4):375–81. X-121359119
96 Blankenship K, Minshawi NF. Behavioral Therapy with an Individual with Asperger’s Disorder. Psychiatry (Edgmont). 2010 Aug;7(8):38–41. X-2, X-3, X-4
97 Blardi P, de Lalla A, Ceccatelli L, . Variations of plasma leptin and adiponectin levels in autistic patients. Neurosci Lett. 2010 Jul 19;479(1):54–7. doi: 10.1016/j.neulet.2010.05.027. X-120478355
98 Blundell J, Blaiss CA, Etherton MR, . Genetic animal models of Autism. Annals of Neurology. 2010;68:S31. doi: http://dx.doi.org/10.1002/ana.22175. X-1
99 Boggio EM, Lonetti G, Pizzorusso T, . Synaptic determinants of Rett syndrome. Frontiers in Synaptic Neuroscience. 2010;(AUG)(Article 28) doi: http://dx.doi.org/10.3389/fnsyn.2010.00028. X-1
100 Bonnel A, McAdams S, Smith B, . Enhanced pure-tone pitch discrimination among persons with autism but not Asperger syndrome. Neuropsychologia. 2010 Jul;48(9):2465–75. doi: 10.1016/j.neuropsychologia.2010.04.020. X-120433857
101 Bonnet-Brilhault F. [Managing an autistic child]. Rev Prat. 2010 Mar 20;60(3):385–8. X-120402134
102 Boso M, Comelli M, Emanuele E, . Seasonal fluctuations in problem behaviors among young adults with autism and intellectual disability. Med Sci Monit. 2010 May;16(5):Cr213–6. X-120424547
103 Boyd BA, Baranek GT, Sideris J, . Sensory features and repetitive behaviors in children with autism and developmental delays. Autism Res. 2010 Apr;3(2):78–87. doi: 10.1002/aur.124. X-120437603
104 Bozdagi O, Sakurai T, Papapetrou D, . Haploinsufficiency of the autism-associated Shank3 gene leads to deficits in synaptic function, social interaction, and social communication. Mol Autism. 2010;1(1):15. doi: 10.1186/2040-2392-1-15. X-121167025
105 Bradford K. Brief education about autism spectrum disorders for family therapists. Journal of Family Psychotherapy. 2010 July;21(3):161–79. doi: http://dx.doi.org/10.1080/08975353.2010.505529. X-1, X-2
106 Brambring M, Asbrock D. Validity of False Belief Tasks in Blind Children. Journal of Autism & Developmental Disorders. 2010;40(12):1471–84 14p. doi: 10.1007/s10803-010-1002-2. Language: English. Entry Date: 20101129. Revision Date: 20150711. Publication Type: Journal Article. X-120379770
107 Brookman-Frazee LI, Taylor R, Garland AF. Characterizing community-based mental health services for children with autism spectrum disorders and disruptive behavior problems. J Autism Dev Disord. 2010 Oct;40(10):1188–201. doi: 10.1007/s10803-010-0976-0. X-120204690
108 Brownlow C. Presenting the self: negotiating a label of autism. J Intellect Dev Disabil. 2010 Mar;35(1):14–21. doi: 10.3109/13668250903496336. X-120121662
109 Burke LM, Kalpakjian CZ, Smith YR, . Gynecologic issues of adolescents with Down syndrome, autism, and cerebral palsy. J Pediatr Adolesc Gynecol. 2010 Feb;23(1):11–5. doi: 10.1016/j.jpag.2009.04.005. X-119643648
110 Burke RV, Andersen MN, Bowen SL, . Evaluation of two instruction methods to increase employment options for young adults with autism spectrum disorders. Res Dev Disabil. 2010 Nov–Dec;31(6):1223–33. doi: 10.1016/j.ridd.2010.07.023. X-120800988
111 Bussing R, Siddiqi S, Janicke DM, . Late onset autistic symptoms and other fluctuating behaviors. J Dev Behav Pediatr. 2010 Apr;31(3 Suppl):S38–41. doi: 10.1097/DBP.0b013e3181db78e3. X-120414073
112 Calhoun V, Wu L, Kiehl K, . Aberrant Processing of Deviant Stimuli in Schizophrenia Revealed by Fusion of FMRI and EEG Data. Acta Neuropsychiatr. 2010 Jun;22(3):127–38. doi: 10.1111/j.1601-5215.2010.00467.x. X-121331320
113 Callahan K, Shukla-Mehta S, Magee S, . ABA versus TEACCH: the case for defining and validating comprehensive treatment models in autism. J Autism Dev Disord. 2010 Jan;40(1):74–88. doi: 10.1007/s10803-009-0834-0. X-119649699
114 Cannon DS, Miller JS, Robison RJ, . Genome-wide linkage analyses of two repetitive behavior phenotypes in Utah pedigrees with autism spectrum disorders. Mol Autism. 2010;1(1):3. doi: 10.1186/2040-2392-1-3. X-120678246
115 Capp PL, de Faria ME, Siqueira SR, . Special care dentistry: Midazolam conscious sedation for patients with neurological diseases. Eur J Paediatr Dent. 2010 Dec;11(4):162–4. X-121250764
116 Carayol J, Schellenberg GD, Tores F, . Assessing the impact of a combined analysis of four common low-risk genetic variants on autism risk. Mol Autism. 2010;1(1):4. doi: 10.1186/2040-2392-1-4. X-120678243
117 Carbone PS, Behl DD, Azor V, . The medical home for children with autism spectrum disorders: parent and pediatrician perspectives. J Autism Dev Disord. 2010 Mar;40(3):317–24. doi: 10.1007/s10803-009-0874-5. X-119768528
118 Carbone PS, Farley M, Davis T. Primary care for children with autism. Am Fam Physician. 2010 Feb 15;81(4):453–60. X-120148499
119 Carbone VJ, Sweeney-Kerwin EJ, Attanasio V, . Increasing the vocal responses of children with autism and developmental disabilities using manual sign mand training and prompt delay. J Appl Behav Anal. 2010 Winter;43(4):705–9. doi: 10.1901/jaba.2010.43-705. X-3, X-421541153
120 Careaga M, Van de Water J, Ashwood P. Immune dysfunction in autism: A pathway to treatment. Neurotherapeutics. 2010 July;7(3):283–92. doi: http://dx.doi.org/10.1016/j.nurt.2010.05.003. X-1, X-2, X-320643381
121 Carroll VS. Newsworthy neuroscience. Journal of Neuroscience Nursing. 2010;42(2):59–60 2p. Language: English. Entry Date: 20100521. Revision Date: 20150819. Publication Type: Journal Article. X-1, X-2
122 Cascio CJ. Somatosensory processing in neurodevelopmental disorders. J Neurodev Disord. 2010 Jun;2(2):62–9. doi: 10.1007/s11689-010-9046-3. X-122127855
123 Casella SE, Wilder DA, Neidert P, . The effects of response effort on safe performance by therapists at an autism treatment facility. J Appl Behav Anal. 2010 Winter;43(4):729–34. doi: 10.1901/jaba.2010.43-729. X-121541157
124 Charania SM, LeBlanc LA, Sabanathan N, . Teaching effective hand raising to children with autism during group instruction. J Appl Behav Anal. 2010 Fall;43(3):493–7. doi: 10.1901/jaba.2010.43-493. X-1, X-3, X-421358908
125 Charman T. Developmental approaches to understanding and treating autism. Folia Phoniatr Logop. 2010;62(4):166–77. doi: 10.1159/000314032. X-120460929
126 Chez MG, Guido-Estrada N. Immune therapy in autism: Historical experience and future directions with immunomodulatory therapy. Neurotherapeutics. 2010 July;7(3):293–301. doi: http://dx.doi.org/10.1016/j.nurt.2010.05.008. X-1, X-2, X-320643382
127 Chisholm K, Gibbons A, Psarros C, . Longitudinal outcomes of early implantation in children with auditory neuropathy spectrum disorder (ANSD). Cochlear Implants Int. 2010 Jun;11(Suppl 1):169–75. doi: 10.1179/146701010x12671177818588. X-121756606
128 Chok JT, Reed DD, Kennedy A, . A single-case experimental analysis of the effects of ambient prism lenses for an adolescent with developmental disabilities. Behav Anal Pract. 2010 Fall;3(2):42–51. X-122532893
129 Christon LM, Mackintosh VH, Myers BJ. Use of complementary and alternative medicine (CAM) treatments by parents of children with autism spectrum disorders. Research in Autism Spectrum Disorders. 2010 April 2010/June;4(2):249–59. doi: http://dx.doi.org/10.1016/j.rasd.2009.09.013. X-1, X-3
130 Clark B, Vandermeer B, Simonetti A, . Is lead a concern in Canadian autistic children? Paediatr Child Health. 2010 Jan;15(1):17–22. X-121197164
131 Clark M, Harris R, Jolleff N, . Worster-Drought syndrome: poorly recognized despite severe and persistent difficulties with feeding and speech. Dev Med Child Neurol. 2010 Jan;52(1):27–32. doi: 10.1111/j.1469-8749.2009.03475.x. X-119824895
132 Coben R, Myers TE. The relative efficacy of connectivity guided and symptom based EEG biofeedback for autistic disorders. Appl Psychophysiol Biofeedback. 2010 Mar;35(1):13–23. doi: 10.1007/s10484-009-9102-5. X-2, X-319649702
133 Coghlan A. Autism drug aims to balance brain signals. New Scientist. 2010;207(2778):01- 1p. Language: English. Entry Date: 20110208. Revision Date: 20150711. Publication Type: Journal Article. Journal Subset: Consumer Health. X-1, X-2
134 Consoli A, Gheorghiev C, Jutard C, . Lorazepam, fluoxetine and packing therapy in an adolescent with pervasive developmental disorder and catatonia. Journal of Physiology Paris. 2010 December;104(6):309–14. doi: http://dx.doi.org/10.1016/j.jphysparis.2010.09.002. X-1, X-3, X-4
135 Constantino JN, Majmudar P, Bottini A, . Infant head growth in male siblings of children with and without autism spectrum disorders. J Neurodev Disord. 2010 Mar;2(1):39–46. doi: 10.1007/s11689-009-9036-5. X-120651949
136 Cook Jr EH. Reduction of increased repetitive self-grooming in ASD mouse model by metabotropic 5 glutamate receptor antagonism; randomized controlled trial of Early Start Denver Model. Autism research : official journal of the International Society for Autism Research. 2010 Feb;3(1):40–2. doi: http://dx.doi.org/10.1002/aur.118. X-120175131
137 Coolican J, Smith IM, Bryson SE. Brief parent training in pivotal response treatment for preschoolers with autism. J Child Psychol Psychiatry. 2010 Dec;51(12):1321–30. doi: 10.1111/j.1469-7610.2010.02326.x. X-3, X-421073457
138 Correia CT, Almeida JP, Santos PE, . Pharmacogenetics of risperidone therapy in autism: association analysis of eight candidate genes with drug efficacy and adverse drug reactions. Pharmacogenomics J. 2010 Oct;10(5):418–30. doi: 10.1038/tpj.2009.63. X-319997080
139 Coury D. Medical treatment of autism spectrum disorders. Current Opinion in Neurology. 2010 April;23(2):131–6. doi: http://dx.doi.org/10.1097/WCO.0b013e32833722fa. X-1, X-220087181
140 Cuvo AJ, Godard A, Huckfeldt R, . Training children with autism spectrum disorders to be compliant with an oral assessment. Research in Autism Spectrum Disorders. 2010 October-December;4(4):681–96. doi: http://dx.doi.org/10.1016/j.rasd.2010.01.007. X-1
141 Czapanskiy KS. Chalimony: seeking equity between parents of children with disabilities and chronic illnesses. Rev Law Soc Change. 2010;34(2):253–98. X-120722202
142 Darrou C, Pry R, Pernon E, . Outcome of young children with autism: does the amount of intervention influence developmental trajectories? Autism. 2010 Nov;14(6):663–77. doi: 10.1177/1362361310374156. X-1, X-321149421
143 Davidson J. ‘It cuts both ways’: a relational approach to access and accommodation for autism. Soc Sci Med. 2010 Jan;70(2):305–12. doi: 10.1016/j.socscimed.2009.10.017. X-119883964
144 Davies PL, Tucker R. Evidence Review to Investigate the Support for Subtypes of Children With Difficulty Processing and Integrating Sensory Information. American Journal of Occupational Therapy. 2010;64(3):391–402 12p. doi: 10.5014/ajot.2010.09070. Language: English. Entry Date: 20130221. Revision Date: 20150711. Publication Type: Journal Article. X-120608271
145 Dawson G, Rogers S, Munson J, . Randomized, controlled trial of an intervention for toddlers with autism: the Early Start Denver Model. Pediatrics. 2010 Jan;125(1):e17–23. doi: 10.1542/peds.2009-0958. X-119948568
146 de Bruijn DR, van Dijk AH, Pfundt R, . Severe Progressive Autism Associated with Two de novo Changes: A 2.6-Mb 2q31.1 Deletion and a Balanced t(14;21)(q21.1;p11.2) Translocation with Long-Range Epigenetic Silencing of LRFN5 Expression. Mol Syndromol. 2010 Feb;1(1):46–57. doi: 10.1159/000280290. X-120648246
147 De Filippis B, Ricceri L, Laviola G. Investigating rett syndrome through genetic mouse models: Presymptomatic, clearly symptomatic phases, and innovative therapeutic approaches. In: Kalueff AV, Bergner CL, eds. Transgenic and Mutant Tools to Model Brain Disorders. 999 Riverview Drive, Suite 208, Totowa NJ 07512–1165, United States: Humana Press; 2010:151–78.
148 de Los Reyes EC. Autism and immunizations: separating fact from fiction. Arch Neurol. 2010 Apr;67(4):490–2. doi: 10.1001/archneurol.2010.57. X-1, X-220385917
149 De Schipper JC, Schuengel C. Attachment behaviour towards support staff in young people with intellectual disabilities: associations with challenging behaviour. J Intellect Disabil Res. 2010 Jul;54(7):584–96. doi: 10.1111/j.1365-2788.2010.01288.x. X-120492348
150 Desousa A. An Open-label Trial of Risperidone and Fluoxetine in Children with Autistic Disorder. Indian J Psychol Med. 2010 Jan;32(1):17–21. doi: 10.4103/0253-7176.70522. X-121799554
151 Desruisseaux MS, Iacobas DA, Iacobas S, . Alterations in the Brain Transcriptome in ANKA Infected Mice. J Neuroparasitology. 2010 Oct;1. X-1
152 Deutsch SI, Urbano MR, Neumann SA, . Cholinergic abnormalities in autism: Is there a rationale for selective nicotinic agonist interventions? Clinical Neuropharmacology. 2010 May;33(3):114–20. doi: http://dx.doi.org/10.1097/WNF.0b013e3181d6f7ad. X-120190638
153 Dias GG, Prado EF, Vadasz E, . Evaluation of the efficacy of a dental plaque control program in autistic patients. J Autism Dev Disord. 2010 Jun;40(6):704–8. doi: 10.1007/s10803-009-0918-x. X-120052608
154 Dichter GS, Benning SD, Holtzclaw TN, . Affective modulation of the startle eyeblink and postauricular reflexes in autism spectrum disorder. J Autism Dev Disord. 2010 Jul;40(7):858–69. doi: 10.1007/s10803-009-0925-y. X-120049632
155 Dichter GS, Radonovich KJ, Turner-Brown LM, . Performance of children with autism spectrum disorders on the Dimension-Change Card Sort task. Journal of Autism & Developmental Disorders. 2010;40(4):448–56 9p. doi: 10.1007/s10803-009-0886-1. Language: English. Entry Date: 20100430. Revision Date: 20150711. Publication Type: Journal Article. X-119890707
156 Dichter GS, Sikich L, Mahorney S, . fMRI tracks reductions in repetitive behaviors in autism: two case studies. Neurocase (Psychology Press). 2010;16(4):307–16 10p. doi: 10.1080/13554790903559671. Language: English. Entry Date: 20101022. Revision Date: 20150711. Publication Type: Journal Article. X-1, X-3, X-4
157 Dickstein DP. In this issue/abstract thinking: the new normal. J Am Acad Child Adolesc Psychiatry. 2010 Nov;49(11):1087–8. doi: 10.1016/j.jaac.2010.08.010. X-120970695
158 Dillon SR, Casebolt KM, Tindall DW, . Digest. Adapted Physical Activity Quarterly. 2010;27(3):261–5 5p. Language: English. Entry Date: 20100813. Revision Date: 20150711. Publication Type: Journal Article. X-1
159 Dowd AM, Rinehart NJ, McGinley J. Motor function in children with autism: Why is this relevant to psychologists? Clinical Psychologist. 2010;14(3):90–6 7p. doi: 10.1080/13284207.2010.525532. Language: English. Entry Date: 20101216. Revision Date: 20150711. Publication Type: Journal Article. X-1
160 Drahota A, Chavira DA, Stein MT. Ian: a 7-year old with prenatal drug exposure and early exposure to family violence. J Dev Behav Pediatr. 2010 Apr;31(3 Suppl):S3–6. doi: 10.1097/DBP.0b013e3181d82fa7. X-120414070
161 Dufour-Rainfray D, Vourc’h P, Le Guisquet AM, . Behavior and serotonergic disorders in rats exposed prenatally to valproate: A model for autism. Neuroscience Letters. 2010 05 Feb;470(1):55–9. doi: http://dx.doi.org/10.1016/j.neulet.2009.12.054. X-120036713
162 Dunst CJ, Trivette CM, Masiello T. Influence of the interests of children with autism on everyday learning opportunities. Psychol Rep. 2010 Aug;107(1):281–8. doi: 10.2466/04.10.11.15.21.pr0.107.4.281-288. X-120923073
163 Eby CM, Greer RD, Tullo LD, . Effects of multiple exemplar instruction on transformation of stimulus function across written and vocal spelling responses by students with autism. The Journal of Speech and Language Pathology – Applied Behavior Analysis. 2010 2015-12-09;5(1):20–31. doi: http://dx.doi.org/10.1037/h0100262; 2014-51868-002. X-1
164 Einspieler C, Marschik PB, Prechtl HF. [What do early childhood movements tell us?]. Kinderkrankenschwester. 2010 Sep;29(9):389–92. X-120942313
165 Ekinci O, Arman AR, Isik U, . EEG abnormalities and epilepsy in autistic spectrum disorders: Clinical and familial correlates. Epilepsy and Behavior. 2010 February;17(2):178–82. doi: http://dx.doi.org/10.1016/j.yebeh.2009.11.014. X-120042370
166 Eklund M, Ostman M. Belonging and doing: important factors for satisfaction with sexual relations as perceived by people with persistent mental illness. Int J Soc Psychiatry. 2010 Jul;56(4):336–47. doi: 10.1177/0020764008101635. X-119617283
167 Elvins R, Green J. Pharmacological management of core and comorbid symptoms in autism-spectrum disorder. Advances in Psychiatric Treatment. 2010 September;16(5):349–60. doi: http://dx.doi.org/10.1192/apt.bp.108.005538. X-1, X-2, X-3
168 Emanuele E, Colombo R, Martinelli V, . Elevated urine levels of bufotenine in patients with autistic spectrum disorders and schizophrenia. Neuroendocrinology Letters. 2010;31(1):117–21. X-120150873
169 Enticott PG, Rinehart NJ, Tonge BJ, . A preliminary transcranial magnetic stimulation study of cortical inhibition and excitability in high-functioning autism and Asperger disorder. Dev Med Child Neurol. 2010 Aug;52(8):e179–83. doi: 10.1111/j.1469-8749.2010.03665.x. X-120370810
170 Erickson CA, Mullett JE, McDougle CJ. Brief report: Acamprosate in fragile X syndrome. Journal of Autism and Developmental Disorders. 2010 November;40(11):1412–6. doi: http://dx.doi.org/10.1007/s10803-010-0988-9. X-120213249
171 Erickson CA, Stigler KA, Posey DJ, . Aripiprazole in autism spectrum disorders and fragile X syndrome. Neurotherapeutics. 2010 July;7(3):258–63. doi: http://dx.doi.org/10.1016/j.nurt.2010.04.001. X-1, X-2, X-320643378
172 Esch JW, Esch BE, McCart JD, . An assessment of self-echoic behavior in young children. Anal Verbal Behav. 2010;26(1):3–13. X-122477458
173 Faber A, Kalverdijk LJ, de Jong-van den Berg LT, . Co-morbidity and patterns of care in stimulant-treated children with ADHD in the Netherlands. Eur Child Adolesc Psychiatry. 2010 Feb;19(2):159–66. doi: 10.1007/s00787-009-0075-y. X-119894075
174 Falcomata TS, Roane HS, Feeney BJ, . Assessment and treatment of elopement maintained by access to stereotypy. J Appl Behav Anal. 2010 Fall;43(3):513–7. doi: 10.1901/jaba.2010.43-513. X-1, X-321358912
175 Farr W, Yuill N, Raffle H. Social benefits of a tangible user interface for children with Autistic Spectrum Conditions. Autism. 2010 May;14(3):237–52. doi: 10.1177/1362361310363280. X-120484323
176 Fernandes FD, Santos TH, Amato CA, . Computerized resources in language therapy with children of the autistic spectrum. Pro Fono. 2010 Oct–Dec;22(4):415–20. X-321271092
177 Fernell E, Gillberg C. Autism spectrum disorder diagnoses in Stockholm preschoolers. Res Dev Disabil. 2010 May–Jun;31(3):680–5. doi: 10.1016/j.ridd.2010.01.007. X-120149593
178 Finnigan E, Starr E. Increasing social responsiveness in a child with autism. A comparison of music and non-music interventions. Autism. 2010 Jul;14(4):321–48. doi: 10.1177/1362361309357747. X-3, X-420591958
179 Forbes F, Merriman H, Sparrow N. SIGN guideline on ADHD/HKD updates treatment options. Guidelines in Practice. 2010;13(2):31–41 9p. Language: English. Entry Date: 20100618. Revision Date: 20150711. Publication Type: Journal Article. X-1, X-2
180 Foss-Feig JH, Kwakye LD, Cascio CJ, . An extended multisensory temporal binding window in autism spectrum disorders. Exp Brain Res. 2010 Jun;203(2):381–9. doi: 10.1007/s00221-010-2240-4. X-120390256
181 Fournier KA, Hass CJ, Naik SK, . Motor coordination in autism spectrum disorders: a synthesis and meta-analysis. Journal of Autism & Developmental Disorders. 2010;40(10):1227–40 14p. doi: 10.1007/s10803-010-0981-3. Language: English. Entry Date: 20101119. Revision Date: 20150711. Publication Type: Journal Article. X-1, X-220195737
182 Frankel F, Myatt R, Sugar C, . A randomized controlled study of parent-assisted Children’s Friendship Training with children having autism spectrum disorders. J Autism Dev Disord. 2010 Jul;40(7):827–42. doi: 10.1007/s10803-009-0932-z. X-1, X-320058059
183 Frazier TW, Youngstrom EA, Haycook T, . Effectiveness of medication combined with intensive behavioral intervention for reducing aggression in youth with autism spectrum disorder. J Child Adolesc Psychopharmacol. 2010 Jun;20(3):167–77. doi: 10.1089/cap.2009.0048. X-1, X-320578929
184 Fries A. [Adult psychiatry makes wrong assessment of autism spectrum conditions. Correct diagnosis can protect against serious therapeutic errors]. Lakartidningen. 2010 Oct 27–Nov 2;107(43):2660–1. X-121137538
185 Frye RE, Butler I, Strickland D, . Electroencephalogram discharges in atypical cognitive development. J Child Neurol. 2010 May;25(5):556–66. doi: 10.1177/0883073809344743. X-120299700
186 Frye RE, Huffman LC, Elliott GR. Tetrahydrobiopterin as a novel therapeutic intervention for autism. Neurotherapeutics. 2010 July;7(3):241–9. doi: http://dx.doi.org/10.1016/j.nurt.2010.05.004. X-1, X-2, X-320643376
187 Fuentes CT, Mostofsky SH, Bastian AJ. Perceptual reasoning predicts handwriting impairments in adolescents with autism. Neurology. 2010;75(20):1825–9 5p. doi: 10.1212/WNL.0b013e3181fd633d. Language: English. Entry Date: 20110107. Revision Date: 20150711. Publication Type: Journal Article. X-121079184
188 Fujikawa-Brooks S, Isenberg AL, Osann K, . The effect of rate stress on the auditory brainstem response in autism: a preliminary report. Int J Audiol. 2010 Feb;49(2):129–40. doi: 10.3109/14992020903289790. X-120151887
189 Gal E, Dyck MJ, Passmore A. Relationships Between Stereotyped Movements and Sensory Processing Disorders in Children With and Without Developmental or Sensory Disorders. American Journal of Occupational Therapy. 2010;64(3):453–61 9p. doi: 10.5014/ajot.2010.09075. Language: English. Entry Date: 20130221. Revision Date: 20150711. Publication Type: Journal Article. X-120608276
190 Gallagher CM, Goodman MS. Hepatitis B vaccination of male neonates and autism diagnosis, NHIS 1997–2002. J Toxicol Environ Health A. 2010;73(24):1665–77. doi: 10.1080/15287394.2010.519317. X-121058170
191 Ganz JB, Lashley E, Rispoli MJ. Non-responsiveness to intervention: children with autism spectrum disorders who do not rapidly respond to communication interventions. Dev Neurorehabil. 2010;13(6):399–407. doi: 10.3109/17518423.2010.508298. X-3, X-421034281
192 Garcia-Villamisar DA, Dattilo J. Effects of a leisure programme on quality of life and stress of individuals with ASD. J Intellect Disabil Res. 2010 Jul;54(7):611–9. doi: 10.1111/j.1365-2788.2010.01289.x. X-120500784
193 Gentry T, Wallace J, Kvarfordt C, . Personal digital assistants as cognitive aids for high school students with autism: results of a community-based trial. Journal of Vocational Rehabilitation. 2010;32(2):101–7 7p. doi: 10.3233/JVR-2010-0499. Language: English. Entry Date: 20100611. Revision Date: 20150819. Publication Type: Journal Article. X-1, X-3
194 Ghaffari M, West SH, Malone RP, . The effects of olanzapine on QTc in children with autistic disorder. Journal of Child and Adolescent Psychopharmacology. 2010 December;20 (6):532. doi: http://dx.doi.org/10.1089/cap.2010.2064. X-2
195 Ghanizadeh A. Transplantation of GABAergic cell line as a novel hypothesized treatment for autism. Epilepsy Behav. 2010 Dec;19(4):664. doi: 10.1016/j.yebeh.2010.09.009. X-120934920
196 Ghanizadeh A. Methionine sulfoximine may improve inflammation in autism, a novel hypothesized treatment for autism. Arch Med Res. 2010 Nov;41(8):651–2. doi: 10.1016/j.arcmed.2010.10.012. X-2, X-321199736
197 Ghanizadeh A. Possible role of caffeine in autism spectrum disorders, a new testable hypothesis. J Food Sci. 2010 Aug 1;75(6):ix. doi: 10.1111/j.1750-3841.2010.01760.x. X-1
198 Ghanizadeh A. Clinical approach to motor stereotypies in autistic children. Iran J Pediatr. 2010 Jun;20(2):149–59. X-123056697
199 Ghanizadeh A. Targeting neurotensin as a potential novel approach for the treatment of autism. Journal of Neuroinflammation. 2010 01 Oct;7(58) doi: http://dx.doi.org/10.1186/1742-2094-7-58. X-1, X-2
200 Ghanizadeh A. A novel explanation for potential toxic effects of valproic acid on creatine: Implications for autism. Molecular Genetics and Metabolism. 2010 October;101(2–3):304. doi: http://dx.doi.org/10.1016/j.ymgme.2010.07.019. X-120728386
201 Gika AD, Hughes E, Goyal S, . Trihexyphenidyl for acute life-threatening episodes due to a dystonic movement disorder in Rett syndrome. Movement Disorders. 2010 15 Feb;25(3):385–9. doi: http://dx.doi.org/10.1002/mds.22926. X-120063434
202 Gjaerum RG, Ineland J, Sauer L. The story about theater organizations, the public’s approval, and the actors’ identity formation in Nordic disability theater. J Soc Work Disabil Rehabil. 2010;9(4):254–73. doi: 10.1080/1536710x.2010.523648. X-121104515
203 Glance JM, Maniloff DJ. Oral motor and articulation therapy for the ASD population…CASPLA Conference 2010, Whitehorse, Yukon, May 19 to 22, 2010. Canadian Journal of Speech-Language Pathology & Audiology. 2010 Spring2010;34(1):59- 1p. Language: English. Entry Date: 20100514. Revision Date: 20150711. Publication Type: Journal Article. X-1
204 Golan O, Ashwin E, Granader Y, . Enhancing emotion recognition in children with autism spectrum conditions: an intervention using animated vehicles with real emotional faces. J Autism Dev Disord. 2010 Mar;40(3):269–79. doi: 10.1007/s10803-009-0862-9. X-1, X-319763807
205 Granpeesheh D, Tarbox J, Dixon DR, . Randomized trial of hyperbaric oxygen therapy for children with autism. Research in Autism Spectrum Disorders. 2010 April 2010/June;4(2):268–75. doi: http://dx.doi.org/10.1016/j.rasd.2009.09.014.
206 Green J, Charman T, McConachie H, . Parent-mediated communication-focused treatment in children with autism (PACT): a randomised controlled trial. Lancet. 2010 Jun 19;375(9732):2152–60. doi: 10.1016/s0140-6736(10)60587-9. X-120494434
207 Green JJ, Hollander E. Autism and oxytocin: New developments in translational approaches to therapeutics. Neurotherapeutics. 2010 July;7(3):250–7. doi: http://dx.doi.org/10.1016/j.nurt.2010.05.006. X-1, X-2, X-320643377
208 Green SA, Ben-Sasson A. Anxiety disorders and sensory over-responsivity in children with autism spectrum disorders: Is there a causal relationship? Journal of Autism and Developmental Disorders. 2010 2015-12-09;40(12):1495–504. doi: http://dx.doi.org/10.1007/s10803-010-1007-x; 2010-23786-007. X-120383658
209 Greenberger C, Serper MR. Examination of clinical and cognitive insight in acute schizophrenia patients. J Nerv Ment Dis. 2010 Jul;198(7):465–9. doi: 10.1097/NMD.0b013e3181e4f35d. X-120611048
210 Grether JK, Li SX, Yoshida CK, . Antenatal ultrasound and risk of autism spectrum disorders. J Autism Dev Disord. 2010 Feb;40(2):238–45. doi: 10.1007/s10803-009-0859-4. X-119728066
211 Groskreutz NC, Karsina A, Miguel CF, . Using complex auditory-visual samples to produce emergent relations in children with autism. J Appl Behav Anal. 2010 Mar;43(1):131–6. doi: 10.1901/jaba.2010.43-131. X-1, X-3, X-420808504
212 Guastella AJ, Einfeld SL, Gray KM, . Intranasal oxytocin improves emotion recognition for youth with autism spectrum disorders. Biol Psychiatry. 2010 Apr 1;67(7):692–4. doi: 10.1016/j.biopsych.2009.09.020. X-1, X-419897177
213 Gulsrud AC, Jahromi LB, Kasari C. The co-regulation of emotions between mothers and their children with autism. J Autism Dev Disord. 2010 Feb;40(2):227–37. doi: 10.1007/s10803-009-0861-x. X-1, X-319714458
214 Gupta S. Antibodies: basic mechanisms and emerging concepts. J Clin Immunol. 2010 May;30(Suppl 1):S1–3. doi: 10.1007/s10875-010-9395-4. X-1
215 Gupta S, Samra D, Agrawal S. Adaptive and innate immune responses in autism: Rationale for therapeutic use of intravenous immunoglobulin. Journal of Clinical Immunology. 2010 May;30(SUPPL. 1):S90–S6. doi: http://dx.doi.org/10.1007/s10875-010-9402-9. X-1, X-220393790
216 Hadjikhani N. Serotonin, pregnancy and increased autism prevalence: is there a link? Med Hypotheses. 2010 May;74(5):880–3. doi: 10.1016/j.mehy.2009.11.015. X-120018455
217 Hagerman R, Hoem G, Hagerman P. Fragile X and autism: Intertwined at the molecular level leading to targeted treatments. Molecular Autism. 2010;1(1) doi: http://dx.doi.org/10.1186/2040-2392-1-12. X-1
218 Hamad CD, Serna RW, Morrison L, . Extending the Reach of Early Intervention Training for Practitioners: A Preliminary Investigation of an Online Curriculum for Teaching Behavioral Intervention Knowledge in Autism to Families and Service Providers. Infants Young Child. 2010 Jul 1;23(3):195–208. doi: 10.1097/IYC.0b013e3181e32d5e. X-123504540
219 Hampel OA, Schaadt AK, Hasmann SE, . [Evaluation of Stepping Stones Triple P: Interims analysis of the Stepping-Stones-SPC-Multicentric Study]. Klin Padiatr. 2010 Jan–Feb;222(1):18–25. doi: 10.1055/s-0029-1243161. X-520084587
220 Hamre HJ, Witt CM, Kienle GS, . Anthroposophic therapy for attention deficit hyperactivity: a two-year prospective study in outpatients. Int J Gen Med. 2010;3:239–53. X-120830200
221 Harony H, Wagner S. The contribution of oxytocin and vasopressin to mammalian social behavior: Potential role in autism spectrum disorder. NeuroSignals. 2010 February;18(2):82–97. doi: http://dx.doi.org/10.1159/000321035. X-121150165
222 Hartley-McAndrew M, Weinstock A. Autism Spectrum Disorder: Correlation between aberrant behaviors, EEG abnormalities and seizures. Neurol Int. 2010;2(1):e10. doi: 10.4081/ni.2010.e10. X-121577334
223 Heinicke MR, Carr JE, Leblanc LA, . On the use of fluency training in the behavioral treatment of autism: a commentary. Behav Anal. 2010 Fall;33(2):223–9. X-122532717
224 Hendy HM, Williams KE, Riegel K, . Parent mealtime actions that mediate associations between children’s fussy-eating and their weight and diet. Appetite. 2010 Feb;54(1):191–5. doi: 10.1016/j.appet.2009.10.006. X-119887094
225 Henning OJ, Nakken KO. Psychiatric comorbidity and use of psychotropic drugs in epilepsy patients. Acta Neurol Scand Suppl. 2010:(190)18–22. doi: 10.1111/j.1600-0404.2010.01370.x. X-120586730
226 Herbert MR. Contributions of the environment and environmentally vulnerable physiology to autism spectrum disorders. Current Opinion in Neurology. 2010 April;23(2):103–10. doi: http://dx.doi.org/10.1097/WCO.0b013e328336a01f. X-120087183
227 Herguner S. Excessive masturbation associated with olanzapine in a pediatric case. Progress in Neuro-Psychopharmacology and Biological Psychiatry. 2010 October;34(7):1349–50. doi: http://dx.doi.org/10.1016/j.pnpbp.2010.06.017. X-120600465
228 Hintzen A, Delespaul P, van Os J, . Social needs in daily life in adults with Pervasive Developmental Disorders. Psychiatry Res. 2010 Aug 30;179(1):75–80. doi: 10.1016/j.psychres.2010.06.014. X-120638732
229 Hobson RP. Explaining autism: Ten reasons to focus on the developing self. Autism. 2010 Sep;14(5):391–407. doi: 10.1177/1362361310364142. X-120926456
230 Hochhauser M, Engel-Yeger B. Sensory processing abilities and their relation to participation in leisure activities among children with high-functioning autism spectrum disorder (HFASD). Research in Autism Spectrum Disorders. 2010 2015-12-09;4(4):746–54. doi: 10.5014/ajot.62.5.554 http://dx.doi.org/10.1016/j.rasd.2010.01.015; 2010-11895-023. X-1
231 Hoekstra PJ, Troost PW, Lahuis BE, . Risperidone-induced weight gain in referred children with autism spectrum disorders is associated with a common polymorphism in the 5-hydroxytryptamine 2C receptor gene. J Child Adolesc Psychopharmacol. 2010 Dec;20(6):473–7. doi: 10.1089/cap.2009.0071. X-1, X-321186965
232 Hoglund Carlsson L, Gillberg C, Lannero E, . Autism: screening toddlers with CHAT in a child health care programme did not improve early identification. Acta Paediatr. 2010 Dec;99(12):1897–9. doi: 10.1111/j.1651-2227.2010.01958.x. X-120670307
233 Holland CD. Autism, insurance, and the idea: providing a comprehensive legal framework. Cornell Law Rev. 2010 Sep;95(6):1253–82. X-120939148
234 Hollander E, Chaplin W, Soorya L, . Divalproex sodium vs placebo for the treatment of irritability in children and adolescents with autism spectrum disorders. Neuropsychopharmacology. 2010 Mar;35(4):990–8. doi: 10.1038/npp.2009.202.20010551
235 Hollenweger J. MHADIE’s matrix to analyse the functioning of education systems. Disabil Rehabil. 2010;32(Suppl 1):S116–24. doi: 10.3109/09638288.2010.520809. X-120874661
236 Huang SC, Tsai SJ, Yang HJ. Aripiprazole improves social interaction in taiwanese children with pervasive developmental disorder. Chang Gung Medical Journal. 2010 March–April;33(2):211–5. X-3, X-420438675
237 Huemer SV, Mann V. A Comprehensive Profile of Decoding and Comprehension in Autism Spectrum Disorders. J Autism Dev Disord. 2010 Apr;40(4):485–93. doi: 10.1007/s10803-009-0892-3. X-119915968
238 Huhtanen S. Helping your child build strength: looking outside the box. Exceptional Parent. 2010;40(5):60- 1p. Language: English. Entry Date: 20100618. Revision Date: 20150711. Publication Type: Journal Article. Journal Subset: Consumer Health. X-1
239 Hurwitz R, Blackmore R, Woolfenden S, . Tricyclic antidepressants in autism - A cochrane systematic review. Journal of Paediatrics and Child Health. 2010 March;46:7. doi: http://dx.doi.org/10.1111/j.1440-1754.2010.01722.x. X-1, X-2
240 Hwang SJ, Chen YS. Congenital Rubella Syndrome With Autistic Disorder. Journal of the Chinese Medical Association. 2010 February;73(2):104–7. doi: http://dx.doi.org/10.1016/S1726-4901%2810%2970011-3. X-120171592
241 Iarocci G, Rombough A, Yager J, . Visual influences on speech perception in children with autism. Autism. 2010 Jul;14(4):305–20. doi: 10.1177/1362361309353615. X-1, X-320591957
242 Ingersoll B. Pilot randomized controlled trial of Reciprocal Imitation Training for teaching elicited and spontaneous imitation to children with autism. J Autism Dev Disord. 2010 Sep;40(9):1154–60. doi: 10.1007/s10803-010-0966-2. X-120155309
243 Ingersoll B, Lalonde K. The impact of object and gesture imitation training on language use in children with autism spectrum disorder. J Speech Lang Hear Res. 2010 Aug;53(4):1040–51. doi: 10.1044/1092-4388(2009/09-0043). X-3, X-420631228
244 Jackett JM. Transition and beyond for individuals with autism spectrum disorders (ASD): a New Jersey case study of the adult service sector, its inherent shortcomings, and hope for the future. Seton Hall Law Rev. 2010;40(4):1733–74. X-121280391
245 Jafferany M, Shireen F, Ibrahim A. An open-label trial of topiramate in the treatment of skin picking in pervasive developmental disorder not otherwise specified. Prim Care Companion J Clin Psychiatry. 2010;12(2) doi: 10.4088/PCC.09l00829yel. X-1
246 James WH. Behavioural and biological determinants of human sex ratio at birth. J Biosoc Sci. 2010 Sep;42(5):587–99. doi: 10.1017/s002193201000012x. X-120519063
247 Janusis GM, Weyandt LL. An exploratory study of substance use and misuse among college students with and without ADHD and other disabilities. J Atten Disord. 2010 Nov;14(3):205–15. doi: 10.1177/1087054710367600. X-120479474
248 Jarrold C, Mansergh R, Whiting C. The representational status of pretence: evidence from typical development and autism. British Journal of Developmental Psychology. 2010;28(2):239–54 16p. doi: 10.1348/026151008X400085. Language: English. Entry Date: 20100709. Revision Date: 20150711. Publication Type: Journal Article. X-120481386
249 Johnson SA, Blaha LM, Houpt JW, . Systems Factorial Technology provides new insights on global-local information processing in autism spectrum disorders. J Math Psychol. 2010 Feb;54(1):53–72. doi: 10.1016/j.jmp.2009.06.006. X-123750050
250 Jones AT, Kildea S, Hunt J, . Book reviews. Clinical Child Psychology & Psychiatry. 2010;15(1):129–43 15p. doi: 10.1177/1359104509348671. Language: English. Entry Date: 20100416. Revision Date: 20150711. Publication Type: Journal Article. X-1
251 Jordan CJ. Evolution of autism support and understanding via the World Wide Web. Intellect Dev Disabil. 2010 Jun;48(3):220–7. doi: 10.1352/1934-9556-48.3.220. X-120597733
252 Joshi G, Petty C, Wozniak J, . The heavy burden of psychiatric comorbidity in youth with autism spectrum disorders: a large comparative study of a psychiatrically referred population. J Autism Dev Disord. 2010 Nov;40(11):1361–70. doi: 10.1007/s10803-010-0996-9. X-120309621
253 Jyonouchi H. Autism spectrum disorders and allergy: observation from a pediatric allergy/immunology clinic. Expert Rev Clin Immunol. 2010 May;6(3):397–411. doi: 10.1586/eci.10.18. X-120441426
254 Kallstrand J, Olsson O, Nehlstedt SF, . Abnormal auditory forward masking pattern in the brainstem response of individuals with Asperger syndrome. Neuropsychiatr Dis Treat. 2010;6:289–96. X-120628629
255 Kamp-Becker I, Schroder J, Remschmidt H, . Health-related quality of life in adolescents and young adults with high functioning autism-spectrum disorder. Psychosoc Med. 2010;7 doi: 10.3205/psm000065. X-1
256 Karakaya P, Yis U, Kurul SH, . Rhabdomyolysis associated with olanzapine treatment in a child with Autism. Pediatric Emergency Care. 2010;26(1):41–2 2p. doi: 10.1097/PEC.0b013e3181c39a22. Language: English. Entry Date: 20100416. Revision Date: 20150711. Publication Type: Journal Article. X-1, X-3, X-420065830
257 Karanth P, Shaista S, Srikanth N. Efficacy of communication DEALL--an indigenous early intervention program for children with autism spectrum disorders. Indian J Pediatr. 2010 Sep;77(9):957–62. doi: 10.1007/s12098-010-0144-8. X-320821283
258 Kasari C, Gulsrud AC, Wong C, . Randomized controlled caregiver mediated joint engagement intervention for toddlers with autism. J Autism Dev Disord. 2010 Sep;40(9):1045–56. doi: 10.1007/s10803-010-0955-5. X-120145986
259 Keane BP, Rosenthal O, Chun NH, . Audiovisual integration in high functioning adults with autism. Research in Autism Spectrum Disorders. 2010 2015-12-09;4(2):276–89. doi: http://dx.doi.org/10.1016/j.rasd.2009.09.015; 2011-03277-014. X-1
260 Ketelaars MP, Cuperus J, Jansonius K, . Pragmatic language impairment and associated behavioural problems. Int J Lang Commun Disord. 2010 Mar–Apr;45(2):204–14. doi: 10.3109/13682820902863090. X-122748032
261 Khetrapal N. Overlap of autism and seizures: understanding cognitive comorbidity. Mens Sana Monogr. 2010 Jan;8(1):122–8. doi: 10.4103/0973-1229.58823. X-121327174
262 Kim Y, Cho SC, Shin MS, . Retrospective case series of aripiprazole augmentation in pervasive developmental disorders. Psychiatry Investig. 2010 Sep;7(3):220–3. doi: 10.4306/pi.2010.7.3.220. X-1, X-3
263 Koegel LK, Singh AK, Koegel RL. Improving motivation for academics in children with autism. J Autism Dev Disord. 2010 Sep;40(9):1057–66. doi: 10.1007/s10803-010-0962-6. X-120221791
264 Koenig K, White SW, Pachler M, . Promoting social skill development in children with pervasive developmental disorders: a feasibility and efficacy study. J Autism Dev Disord. 2010 Oct;40(10):1209–18. doi: 10.1007/s10803-010-0979-x. X-120204689
265 Kolar D. Efficacy of risperidone on the core symptoms of autistic disorder. European Neuropsychopharmacology. 2010 August;20:S621. doi: http://dx.doi.org/10.1016/S0924-977X%2810%2970951-2. X-1, X-3
266 Koldewyn K, Whitney D, Rivera SM. The psychophysics of visual motion and global form processing in autism. Brain: A Journal of Neurology. 2010;133(2):599–610 12p. doi: 10.1093/brain/awp272. Language: English. Entry Date: 20100326. Revision Date: 20150711. Publication Type: Journal Article. Journal Subset: Allied Health. X-119887505
267 Kopp S, Beckung E, Gillberg C. Developmental coordination disorder and other motor control problems in girls with autism spectrum disorder and/or attention-deficit/hyperactivity disorder. Res Dev Disabil. 2010 Mar–Apr;31(2):350–61. doi: 10.1016/j.ridd.2009.09.017. X-119910158
268 Koshelev M, Lohrenz T, Vannucci M, . Biosensor approach to psychopathology classification. PLoS Comput Biol. 2010;6(10):e1000966. doi: 10.1371/journal.pcbi.1000966. X-120975934
269 Kozulin A, Lebeer J, Madella-Noja A, . Cognitive modifiability of children with developmental disabilities: a multicentre study using Feuerstein’s Instrumental Enrichment--Basic program. Res Dev Disabil. 2010 Mar–Apr;31(2):551–9. doi: 10.1016/j.ridd.2009.12.001. X-120056377
270 Kream RM, Stefano GB, Ptacek R. Psychiatric implications of endogenous morphine: Up-to-date review. Folia Biologica. 2010;56(6):231–41. X-1, X-221324264
271 Kring SR, Greenberg JS, Seltzer MM. The Impact of Health Problems on Behavior Problems in Adolescents and Adults With Autism Spectrum Disorders: Implications for Maternal Burden. Soc Work Ment Health. 2010 Jan;8(1):54–71. doi: 10.1080/15332980902932441. X-120657702
272 Kroeger K, Sorensen R. A parent training model for toilet training children with autism. J Intellect Disabil Res. 2010 Jun;54(6):556–67. doi: 10.1111/j.1365-2788.2010.01286.x. X-3, X-420576064
273 Kuhn G, Kourkoulou A, Leekam SR. How magic changes our expectations about autism. Psychol Sci. 2010 Oct;21(10):1487–93. doi: 10.1177/0956797610383435. X-120855904
274 Kujala T, Kuuluvainen S, Saalasti S, . Speech-feature discrimination in children with Asperger syndrome as determined with the multi-feature mismatch negativity paradigm. Clin Neurophysiol. 2010 Sep;121(9):1410–9. doi: 10.1016/j.clinph.2010.03.017. X-120382070
275 Kuwagata M, Ogawa T, Shioda S, . Development of offspring brain in a rat valproate-induced autism model. Congenital Anomalies. 2010 December;50 (4):A17. doi: http://dx.doi.org/10.1111/j.1741-4520.2010.00297.x. X-1
276 LaCava PG, Rankin A, Mahlios E, . A single case design evaluation of a software and tutor intervention addressing emotion recognition and social interaction in four boys with ASD. Autism. 2010 May;14(3):161–78. doi: 10.1177/1362361310362085. X-3, X-420488823
277 Lai DK, Barnes G, Fu C, . Autism spectrum disorders and epilepsy in patients referred for electroencephalography. Annals of Neurology. 2010;68:S40-S1. doi: http://dx.doi.org/10.1002/ana.22175. X-1
278 Lam SF, Wong BP, Leung D, . How parents perceive and feel about participation in community activities. The comparison between parents of preschoolers with and without Autism Spectrum Disorders. Autism. 2010 Jul;14(4):359–77. doi: 10.1177/1362361309346558. X-120591960
279 Lambrey S, Falissard B, Martin-Barrero M, . Effectiveness of clozapine for the treatment of aggression in an adolescent with autistic disorder. Journal of Child and Adolescent Psychopharmacology. 2010 01 Feb;20(1):79–80. doi: http://dx.doi.org/10.1089/cap.2009.0057. X-3, X-420166802
280 Lang R, Koegel LK, Ashbaugh K, . Physical exercise and individuals with autism spectrum disorders: A systematic review. Research in Autism Spectrum Disorders. 2010 October–December;4(4):565–76. doi: http://dx.doi.org/10.1016/j.rasd.2010.01.006. X-1, X-2
281 Larson E. Ever vigilant: maternal support of participation in daily life for boys with autism. Phys Occup Ther Pediatr. 2010 Feb;30(1):16–27. doi: 10.3109/01942630903297227. X-120170429
282 Lawrence DH, Alleckson DA, Bjorklund P. Beyond the Roadblocks: Transitioning to Adulthood With Asperger’s Disorder. Archives of Psychiatric Nursing. 2010 August;24(4):227–38. doi: http://dx.doi.org/10.1016/j.apnu.2009.07.004. X-120650368
283 Lee-Mosier J, Waldrop JB. Advisor forum. Alternatives to stimulants for patients with autism. Clinical Advisor. 2010;13(5):48- 1p. Language: English. Entry Date: 20100702. Revision Date: 20150711. Publication Type: Journal Article. X-1, X-2
284 Leew SV, Stein NG, Gibbard WB. Weighted vests’ effect on social attention for toddlers with Autism Spectrum Disorders. Can J Occup Ther. 2010 Apr;77(2):113–24. X-1, X-320464896
285 Lemonnier E, Ben-Ari Y. The diuretic bumetanide decreases autistic behaviour in five infants treated during 3 months with no side effects. Acta Paediatr. 2010 Dec;99(12):1885–8. doi: 10.1111/j.1651-2227.2010.01933.x. X-3, X-420608900
286 Leonard H, Downs J, Jian L, . Valproate and risk of fracture in Rett syndrome. Archives of Disease in Childhood. 2010 June;95(6):444–8. doi: http://dx.doi.org/10.1136/adc.2008.148932. X-120501539
287 Lepach AC, Lehmkuhl G, Petermann F. [Neuropsychological issues in child psychology and child psychiatry]. Prax Kinderpsychol Kinderpsychiatr. 2010;59(7):576–87. doi: 10.13109/prkk.2010.59.7.576. X-120957778
288 Levy ML, Levy KM, Hoff D, . Vagus nerve stimulation therapy in patients with autism spectrum disorder and intractable epilepsy: results from the vagus nerve stimulation therapy patient outcome registry. J Neurosurg Pediatr. 2010 Jun;5(6):595–602. doi: 10.3171/2010.3.peds09153. X-1, X-320515333
289 Lim HA. Effect of “developmental speech and language training through music” on speech production in children with autism spectrum disorders. J Music Ther. 2010 Spring;47(1):2–26. X-120635521
290 Litras S, Moore DW, Anderson A. Using video self-modelled social stories to teach social skills to a young child with autism. Autism Res Treat. 2010;2010:834979. doi: 10.1155/2010/834979. X-3, X-422937239
291 Lomas JE, Fisher WW, Kelley ME. The effects of variable-time delivery of food items and praise on problem behavior reinforced by escape. J Appl Behav Anal. 2010 Fall;43(3):425–35. doi: 10.1901/jaba.2010.43-425. X-3, X-421358903
292 Lombardo MV, Chakrabarti B, Bullmore ET, . Atypical neural self-representation in autism. Brain: A Journal of Neurology. 2010;133(2):611–24 14p. doi: 10.1093/brain/awp306. Corporate Author: MRC AIMS Consortium. Language: English. Entry Date: 20100326. Revision Date: 20150711. Publication Type: Journal Article. Journal Subset: Allied Health. X-120008375
293 Lopata C, Thomeer ML, Volker MA, . RCT of a manualized social treatment for high-functioning autism spectrum disorders. J Autism Dev Disord. 2010 Nov;40(11):1297–310. doi: 10.1007/s10803-010-0989-8. X-120232240
294 Loth E, Happe F, Gomez JC. Variety is not the spice of life for people with autism spectrum disorders: frequency ratings of central, variable and inappropriate aspects of common real-life events. J Autism Dev Disord. 2010 Jun;40(6):730–42. doi: 10.1007/s10803-009-0929-7. X-120066484
295 Luppanapornlarp S, Leelataweewud P, Putongkam P, . Periodontal status and orthodontic treatment need of autistic children. World J Orthod. 2010 Fall;11(3):256–61. X-120877735
296 Luthy KE, Beckstrand RL, Callister LC. Parental hesitation in immunizing children in Utah. Public Health Nurs. 2010 Jan–Feb;27(1):25–31. doi: 10.1111/j.1525-1446.2009.00823.x. X-120055965
297 Lynch E. Making sense of autism. Nurs Stand. 2010 Sep 15–21;25(2):18–9. X-1
298 Maenner MJ, Durkin MS. Trends in the prevalence of autism on the basis of special education data. Pediatrics. 2010 Nov;126(5):e1018–25. doi: 10.1542/peds.2010-1023. X-120974790
299 Majewska MD, Urbanowicz E, Rok-Bujko P, . Age-dependent lower or higher levels of hair mercury in autistic children than in healthy controls. Acta Neurobiol Exp (Wars). 2010;70(2):196–208. X-120628443
300 Malhotra S, Rajender G, Bhatia MS, . Effects of picture exchange communication system on communication and behavioral anomalies in autism. Indian J Psychol Med. 2010 Jul;32(2):141–3. doi: 10.4103/0253-7176.78513. X-3, X-421716776
301 Malone RP, West SH, Ghaffari M, . Metabolic effects of olanzapine in children with autistic disorder. Journal of Child and Adolescent Psychopharmacology. 2010 December;20 (6):531–2. doi: http://dx.doi.org/10.1089/cap.2010.2064. X-2
302 Mandell DS, Morales KH, Xie M, . Age of diagnosis among Medicaid-enrolled children with autism, 2001–2004. Psychiatr Serv. 2010 Aug;61(8):822–9. doi: 10.1176/appi.ps.61.8.822. X-120675842
303 Markram K, Markram H. The intense world theory - a unifying theory of the neurobiology of autism. Front Hum Neurosci. 2010;4:224. doi: 10.3389/fnhum.2010.00224. X-121191475
304 Marmon P. The map: an innocent interaction with far-reaching outcomes. School Nurse News. 2010 May;27(3):15–6. X-120476529
305 Marr D, Nackley V. Using social stories & sensory stories in autism intervention. OT Practice. 2010;15(10):17–20 4p. Language: English. Entry Date: 20100716. Revision Date: 20150820. Publication Type: Journal Article. X-1
306 Marshall J, Sheller B, Mancl L. Caries-risk assessment and caries status of children with autism. Pediatr Dent. 2010 Jan–Feb;32(1):69–75. X-120298657
307 Martsenkovsky I, Bikshaieva I, Vashenko O, . Memantine therapy of cognitive, behavioral, and social dysfunction in children witch autism spectrum disorders (ASD). International Journal of Neuropsychopharmacology. 2010 June;13:138. doi: http://dx.doi.org/10.1017/S1461145710000635. X-2
308 Matson JL, Boisjoli JA, Hess JA, . Factor structure and diagnostic fidelity of the Baby and Infant Screen for Children with aUtIsm Traits-Part 1 (BISCUIT-part 1). Dev Neurorehabil. 2010;13(2):72–9. doi: 10.3109/17518420903213576. X-120222767
309 Matsuo M, Maeda T, Sasaki K, . Frequent association of autism spectrum disorder in patients with childhood onset epilepsy. Brain Dev. 2010 Oct;32(9):759–63. doi: 10.1016/j.braindev.2010.05.005. X-120542395
310 May-Benson TA, Koomar JA. Systematic review of the research evidence examining the effectiveness of interventions using a sensory integrative approach for children. Am J Occup Ther. 2010 May–Jun;64(3):403–14. X-1, X-220608272
311 McCleery JP, Ceponiene R, Burner KM, . Neural correlates of verbal and nonverbal semantic integration in children with autism spectrum disorders. J Child Psychol Psychiatry. 2010 Mar;51(3):277–86. doi: 10.1111/j.1469-7610.2009.02157.x. X-120025622
312 McCracken JT, Aman MG, McDougle CJ, . Possible influence of variant of the P-glycoprotein gene (MDR1/ABCB1) on clinical response to guanfacine in children with pervasive developmental disorders and hyperactivity. J Child Adolesc Psychopharmacol. 2010 Feb;20(1):1–5. doi: 10.1089/cap.2009.0059. X-1, X-320166790
313 McCravy S, Johnson A, Wetsel MA, . Speak the language of autism. Nurse Practitioner. 2010;35(4):26–34 9p. doi: 10.1097/01.NPR.0000369939.77975.54. Language: English. Entry Date: 20100528. Revision Date: 20150819. Publication Type: Journal Article. X-1, X-2
314 McDuffie A, Yoder P. Types of parent verbal responsiveness that predict language in young children with autism spectrum disorder. J Speech Lang Hear Res. 2010 Aug;53(4):1026–39. doi: 10.1044/1092-4388(2009/09-0023). X-120605942
315 McGonigle-Chalmers M, Alderson-Day B. Free classification as a window on executive functioning in autism spectrum disorders. Journal of Autism & Developmental Disorders. 2010;40(7):844–57 14p. doi: 10.1007/s10803-010-0947-5. Language: English. Entry Date: 20100820. Revision Date: 20150711. Publication Type: Journal Article. X-120108114
316 McGuinness TM, Lewis S. Update on autism and vaccines. J Psychosoc Nurs Ment Health Serv. 2010 Jun;48(6):15–8. doi: 10.3928/02793695-20100506-02. X-1
317 Mehl-Madrona L, Leung B, Kennedy C, . Micronutrients versus standard medication management in autism: a naturalistic case-control study. J Child Adolesc Psychopharmacol. 2010 Apr;20(2):95–103. doi: 10.1089/cap.2009.0011. X-120415604
318 Mesibov GB, Shea V. The TEACCH program in the era of evidence-based practice. J Autism Dev Disord. 2010 May;40(5):570–9. doi: 10.1007/s10803-009-0901-6. X-119937103
319 Michel TM, Sheldrick AJ, Frentzel TG, . [Evaluation of diagnostic and therapeutic services in German university hospitals for adults with autism spectrum disorder (ASD)]. Fortschr Neurol Psychiatr. 2010 Jul;78(7):402–13. doi: 10.1055/s-0029-1245494. X-120607640
320 Molinari JA. Vaccination: science versus perception. Dent Today. 2010 Dec;29(12):84, 6. X-1
321 Monk CS, Weng SJ, Wiggins JL, . Neural circuitry of emotional face processing in autism spectrum disorders. Journal of Psychiatry and Neuroscience. 2010 March;35(2):105–14. doi: http://dx.doi.org/10.1503/jpn.090085. X-120184808
322 Moon M. Can parents of a child with autism refuse treatment for him? Virtual Mentor. 2010;12(11):844–8. doi: 10.1001/virtualmentor.2010.12.11.ccas1-1011. X-123186788
323 Mothander PR, Moe RG. Self-reported depressive symptoms and parental stress in mothers and fathers who bring their infants to an infant mental health clinic. Nord J Psychiatry. 2010 Oct;64(5):310–6. doi: 10.3109/08039480903528138. X-120184497
324 Mrozek-Budzyn D, Kieltyka A, Majewska R. Lack of association between measles-mumps-rubella vaccination and autism in children: a case-control study. Pediatr Infect Dis J. 2010 May;29(5):397–400. doi: 10.1097/INF.0b013e3181c40a8a. X-119952979
325 Mulloy A, Lang R, O’Reilly M, . Gluten-free and casein-free diets in the treatment of autism spectrum disorders: A systematic review. Research in Autism Spectrum Disorders. 2010 July 2010/September;4(3):328–39. doi: http://dx.doi.org/10.1016/j.rasd.2009.10.008. X-1, X-2
326 Murphy C, Barnes-Holmes D. Establishing five derived mands in three adolescent boys with autism. J Appl Behav Anal. 2010 Fall;43(3):537–41. doi: 10.1901/jaba.2010.43-537. X-121358916
327 Murray MJ. Attention-deficit/hyperactivity disorder in the context of autism spectrum disorders. Current Psychiatry Reports. 2010 October;12(5):382–8. doi: http://dx.doi.org/10.1007/s11920-010-0145-3. X-120694583
328 Murza KA, Pavelko SL, Malani MD, . Vitamin B6-magnesium treatment for autism: the current status of the research. Magnesium research : official organ of the International Society for the Development of Research on Magnesium. 2010 Jun;23(2):115–7. X-2
329 Myers SM. Citalopram not effective for repetitive behaviour in autistic spectrum disorders. Evidence Based Mental Health. 2010;13(1):22- 1p. doi: 10.1136/ebmh.13.1.22. Language: English. Entry Date: 20100423. Revision Date: 20150711. Publication Type: Journal Article. X-220164519
330 Narayanan A, White CA, Saklayen S, . Effect of propranolol on functional connectivity in autism spectrum disorder--a pilot study. Brain Imaging Behav. 2010 Jun;4(2):189–97. doi: 10.1007/s11682-010-9098-8. X-1, X-420502989
331 Narita M, Oyabu A, Imura Y, . Nonexploratory movement and behavioral alterations in a thalidomide or valproic acid-induced autism model rat. Neuroscience Research. 2010 January;66(1):2–6. doi: http://dx.doi.org/10.1016/j.neures.2009.09.001. X-119755133
332 Nigro-Bruzzi D, Sturmey P. The effects of behavioral skills training on mand training by staff and unprompted vocal mands by children. J Appl Behav Anal. 2010 Winter;43(4):757–61. doi: 10.1901/jaba.2010.43-757. X-1, X-3, X-421541162
333 Nizamie A, Sengupta U, Mishra BR, . Role of early multimodal interventions in a case with autistic regression. Acta Neurologica Taiwanica. 2010 March;19(1):51–6. X-1, X-3, X-420714953
334 Noterdaeme M, Hutzelmeyer-Nickels A. Early symptoms and recognition of pervasive developmental disorders in Germany. Autism. 2010 Nov;14(6):575–88. doi: 10.1177/1362361310371951. X-120923894
335 Noterdaeme M, Wriedt E, Höhne C. Asperger’s syndrome and high-functioning autism: language, motor and cognitive profiles. European Child & Adolescent Psychiatry. 2010;19(6):475–81 7p. doi: 10.1007/s00787-009-0057-0. Language: English. Entry Date: 20100813. Revision Date: 20150711. Publication Type: Journal Article. X-119813070
336 Oberman LM, Horvath JC, Pascual-Leone A. TMS: using the theta-burst protocol to explore mechanism of plasticity in individuals with Fragile X syndrome and autism. J Vis Exp. 2010(46) doi: 10.3791/2272. X-1, X-2, X-3
337 Olfson M, Crystal S, Huang C, . Trends in antipsychotic drug use by very young, privately insured children. J Am Acad Child Adolesc Psychiatry. 2010 Jan;49(1):13–23. X-120215922
338 Olin AR, Reichle J, Johnson L, . Examining dynamic visual scene displays: implications for arranging and teaching symbol selection. Am J Speech Lang Pathol. 2010 Nov;19(4):284–97. doi: 10.1044/1058-0360(2010/09-0001). X-120581110
339 Ooga K, Abe Y, Okudaira T, . Lamotrigine adjunctive therapy and possible sleep regulation in adult autism spectrum disorder: A case report. European Neuropsychopharmacology. 2010 August;20:S414-S5. doi: http://dx.doi.org/10.1016/S0924-977X%2810%2970595-2. X-1
340 Oosterling I, Visser J, Swinkels S, . Randomized controlled trial of the focus parent training for toddlers with autism: 1-year outcome. J Autism Dev Disord. 2010 Dec;40(12):1447–58. doi: 10.1007/s10803-010-1004-0. X-120440639
341 Owley T, Brune CW, Salt J, . A pharmacogenetic study of escitalopram in autism spectrum disorders. Autism Res. 2010 Feb;3(1):1–7. doi: 10.1002/aur.109. X-320020537
342 Ozguven HD, Oner O, Baskak B, . Theory of Mind in Schizophrenia and Asperger’s Syndrome: Relationship with Negative Symptoms. Klinik Psikofarmakol Bulteni. 2010;20(1):5–13. X-125584026
343 Palmer RF, Walker T, Mandell D, . Explaining low rates of autism among Hispanic schoolchildren in Texas. Am J Public Health. 2010 Feb;100(2):270–2. doi: 10.2105/ajph.2008.150565. X-120019320
344 Pan CY. Effects of water exercise swimming program on aquatic skills and social behaviors in children with autism spectrum disorders. Autism. 2010 Jan;14(1):9–28. doi: 10.1177/1362361309339496. X-420124502
345 Panagiotopoulos C, Ronsley R, Elbe D, . First do no harm: promoting an evidence-based approach to atypical antipsychotic use in children and adolescents. J Can Acad Child Adolesc Psychiatry. 2010 May;19(2):124–37. X-1, X-220467549
346 Pardini M, Guida S, Gialloreti LE. Aripiprazole treatment for coprophagia in autistic disorder. Journal of Neuropsychiatry and Clinical Neurosciences. 2010 Fall;22(4):E33. doi: http://dx.doi.org/10.1176/appi.neuropsych.22.4.451-s.e33. X-1, X-2
347 Parr J. Autism BMJ Clin Evid. 2010;2010. X-2
348 Paul LK, Corsello C, Tranel D, . Does bilateral damage to the human amygdala produce autistic symptoms? J Neurodev Disord. 2010 Sep;2(3):165–73. doi: 10.1007/s11689-010-9056-1. X-120700516
349 Pedrosa E, Shah A, Tenore C, . beta-catenin promoter ChIP-chip reveals potential schizophrenia and bipolar disorder gene network. J Neurogenet. 2010 Dec;24(4):182–93. doi: 10.3109/01677063.2010.495182. X-120615089
350 Peters-Scheffer N, Didden R, Mulders M, . Low intensity behavioral treatment supplementing preschool services for young children with autism spectrum disorders and severe to mild intellectual disability. Res Dev Disabil. 2010 Nov–Dec;31(6):1678–84. doi: 10.1016/j.ridd.2010.04.008. X-120627451
351 Petrovic B, Grzadziel A, Rutonjski L, . Linear array measurements of enhanced dynamic wedge and treatment planning system (TPS) calculation for 15 MV photon beam and comparison with electronic portal imaging device (EPID) measurements. Radiol Oncol. 2010 Sep;44(3):199–206. doi: 10.2478/v10019-010-0037-5. X-122933916
352 Philippe P, Scholl JM, Jacques J. Comorbidity in autism spectrum. Psychiatr Danub. 2010 Nov;22(Suppl 1):S158–60. X-121057429
353 Polanczyk G, Bigarella MP, Hutz MH, . Pharmacogenetic approach for a better drug treatment in children. Current Pharmaceutical Design. 2010;16(22):2462–73. doi: http://dx.doi.org/10.2174/138161210791959872. X-1, X-2, X-320513229
354 Polatajko HJ, Cantin N. Exploring the effectiveness of occupational therapy interventions, other than the sensory integration approach, with children and adolescents experiencing difficulty processing and integrating sensory information. Am J Occup Ther. 2010 May–Jun;64(3):415–29. X-220608273
355 Pop-Jordanova N, Zorcec T, Demerdzieva A, . QEEG characteristics and spectrum weighted frequency for children diagnosed as autistic spectrum disorder. Nonlinear Biomed Phys. 2010;4(1):4. doi: 10.1186/1753-4631-4-4. X-120920283
356 Portoghese C, Buttiglione M, De Giacomo A, . Leiter-R versus developmental quotient for estimating cognitive function in preschoolers with pervasive developmental disorders. Neuropsychiatr Dis Treat. 2010;6:337–42. X-120856598
357 Radhakrishna S. Application of integrated yoga therapy to increase imitation skills in children with autism spectrum disorder. Int J Yoga. 2010 Jan;3(1):26–30. doi: 10.4103/0973-6131.66775. X-3, X-420948898
358 Radhakrishna S, Nagarathna R, Nagendra HR. Integrated approach to yoga therapy and autism spectrum disorders. J Ayurveda Integr Med. 2010 Apr;1(2):120–4. doi: 10.4103/0975-9476.65089. X-1, X-321836799
359 Rajapakse T, Pringsheim T. Pharmacotherapeutics of tourette syndrome and stereotypies in autism. Seminars in Pediatric Neurology. 2010;17(4):254–60 7p. doi: 10.1016/j.spen.2010.10.008. Language: English. Entry Date: 20110512. Revision Date: 20150711. Publication Type: Journal Article. X-1, X-221183132
360 Rao S, Salmon G. Autism spectrum disorders. Br J Hosp Med (Lond). 2010 Dec;71(12):699–703. X-121135768
361 Read N, Schofield A. Autism: are mental health services failing children and parents? J Fam Health Care. 2010;20(4):120–4. X-1, X-221053660
362 Reed P, Osborne LA, Corness M. Effectiveness of special nursery provision for children with autism spectrum disorders. Autism. 2010 Jan;14(1):67–82. doi: 10.1177/1362361309340030. X-120124504
363 Reichow B, Barton EE, Sewell JN, . Effects of weighted vests on the engagement of children with developmental delays and autism. Focus on Autism and Other Developmental Disabilities. 2010 2015-12-09;25(1):3–11. doi: http://dx.doi.org/10.1177/1088357609353751; 2010-02848-001. X-3, X-4
364 Rezaei V, Mohammadi MR, Ghanizadeh A, . Double-blind, placebo-controlled trial of risperidone plus topiramate in children with autistic disorder. Prog Neuropsychopharmacol Biol Psychiatry. 2010 Oct 1;34(7):1269–72. doi: 10.1016/j.pnpbp.2010.07.005.20637249
365 Riquet A, Cuisset JM, Cuvellier JC, . [Characteristics of tuberous sclerosis in children]. Arch Pediatr. 2010 Sep;17(9):1338–45. doi: 10.1016/j.arcped.2010.06.019. X-120709508
366 Rivera-Baltanas T, Romay-Tallon R, Dopeso-Reyes IG, . Serotonin transporter clustering in blood lymphocytes of reeler mice. Cardiovasc Psychiatry Neurol. 2010;2010:396282. doi: 10.1155/2010/396282. X-120414372
367 Robb AS. Managing irritability and aggression in autism spectrum disorders in children and adolescents. Developmental Disabilities Research Reviews. 2010;16(3):258–64. doi: http://dx.doi.org/10.1002/ddrr.118. X-1, X-220981764
368 Robel L. [Medical care organizations for the management of autism in France]. Rev Prat. 2010 Mar 20;60(3):389–90. X-2, X-320402135
369 Roberts D, Pickering N. Parent training programme for autism spectrum disorders: an evaluation. Community Pract. 2010 Oct;83(10):27–30. X-3
370 Roberts TP, Khan SY, Rey M, . MEG detection of delayed auditory evoked responses in autism spectrum disorders: towards an imaging biomarker for autism. Autism Res. 2010 Feb;3(1):8–18. doi: 10.1002/aur.111. X-120063319
371 Rodger S, Ashburner J, Cartmill L, . Helping children with autism spectrum disorders and their families: are we losing our occupation-centred focus? Aust Occup Ther J. 2010 Aug;57(4):276–80. doi: 10.1111/j.1440-1630.2010.00877.x. X-1, X-220854603
372 Rodger S, Vishram A. Mastering social and organization goals: strategy use by two children with Asperger syndrome during cognitive orientation to daily occupational performance. Phys Occup Ther Pediatr. 2010 Nov;30(4):264–76. doi: 10.3109/01942638.2010.500893. X-120822395
373 Romano E, Adriani W, Marco-Lopez EM, . Cannabinoid-induced modulation of behavioural stereotypies induced by amphetamine in a putative mouse model of autism. Behavioural Pharmacology. 2010 September;21 (5–6):592–3. doi: http://dx.doi.org/10.1097/FBP.0b013e32833dbe35. X-1
374 Rosenberg RE, Mandell DS, Farmer JE, . Psychotropic medication use among children with autism spectrum disorders enrolled in a national registry, 2007–2008. J Autism Dev Disord. 2010 Mar;40(3):342–51. doi: 10.1007/s10803-009-0878-1. X-1, X-319806445
375 Roullet FI, Wollaston L, deCatanzaro D, . Behavioral and molecular changes in the mouse in response to prenatal exposure to the anti-epileptic drug valproic acid. Neuroscience. 2010 13 Oct;170(2):514–22. doi: http://dx.doi.org/10.1016/j.neuroscience.2010.06.069. X-120603192
376 Roux JC, Villard L. Biogenic amines in rett syndrome: The usual suspects. Behavior Genetics. 2010 January;40(1):59–75. doi: http://dx.doi.org/10.1007/s10519-009-9303-y. X-119851857
377 Ruble LA, Dalrymple NJ, McGrew JH. The Effects of Consultation on Individualized Education Program Outcomes for Young Children With Autism: The Collaborative Model for Promoting Competence and Success. J Early Interv. 2010 Sep;32(4):286–301. doi: 10.1177/1053815110382973. X-1, X-321691449
378 Russo N, Foxe JJ, Brandwein AB, . Multisensory processing in children with autism: high-density electrical mapping of auditory-somatosensory integration. Autism Res. 2010 Oct;3(5):253–67. doi: 10.1002/aur.152. X-120730775
379 Russo NM, Hornickel J, Nicol T, . Biological changes in auditory function following training in children with autism spectrum disorders. Behav Brain Funct. 2010;6:60. doi: 10.1186/1744-9081-6-60. X-420950487
380 Salamanca AA. Psychotherapy treatment program in a group of adults with high-functioning autism spectrum disorder. Actas Esp Psiquiatr. 2010 Mar–Apr;38(2):94–100. X-120976638
381 Sappok T, Bergmann T, Kaiser H, . [Autism in adults with intellectual disabilities]. Nervenarzt. 2010 Nov;81(11):1333–45. doi: 10.1007/s00115-010-3098-1. X-120857275
382 Sardari D, Maleki R, Samavat H, . Measurement of depth-dose of linear accelerator and simulation by use of Geant4 computer code. Rep Pract Oncol Radiother. 2010;15(3):64–8. doi: 10.1016/j.rpor.2010.03.001. X-124376926
383 Sawyer MG, Bittman M, La Greca AM, . Time demands of caring for children with autism: what are the implications for maternal mental health? J Autism Dev Disord. 2010 May;40(5):620–8. doi: 10.1007/s10803-009-0912-3. X-119949845
384 Sbacchi S, Acquadro F, Calo I, . Functional annotation of genes overlapping copy number variants in autistic patients: focus on axon pathfinding. Curr Genomics. 2010 Apr;11(2):136–45. doi: 10.2174/138920210790886880. X-120885821
385 Scheeren AM, Begeer S, Banerjee R, . Can you tell me something about yourself?: Self-presentation in children and adolescents with high functioning autism spectrum disorder in hypothetical and real life situations. Autism. 2010 Sep;14(5):457–73. doi: 10.1177/1362361310366568. X-120841344
386 Schultz ST. Can autism be triggered by acetaminophen activation of the endocannabinoid system? Acta Neurobiol Exp (Wars). 2010;70(2):227–31. X-120628445
387 Self TL, Hale LS, Crumrine D. Pharmacotherapy and children with autism spectrum disorder: a tutorial for speech-language pathologists. Lang Speech Hear Serv Sch. 2010 Jul;41(3):367–75. doi: 10.1044/0161-1461(2009/08-0106). X-1, X-2, X-320543026
388 Senel HG. Parents’ views and experiences about complementary and alternative medicine treatments for their children with autistic spectrum disorder. J Autism Dev Disord. 2010 Apr;40(4):494–503. doi: 10.1007/s10803-009-0891-4. X-119904598
389 Shapiro JR, Bibat G, Hiremath G, . Bone mass in rett syndrome: Association with clinical parameters and MECP2 mutations. Pediatric Research. 2010 November;68(5):446–51. doi: http://dx.doi.org/10.1203/PDR.0b013e3181f2edd2. X-120661168
390 Shaw W. Increased urinary excretion of a 3-(3-hydroxyphenyl)-3-hydroxypropionic acid (HPHPA), an abnormal phenylalanine metabolite of Clostridia spp. in the gastrointestinal tract, in urine samples from patients with autism and schizophrenia. Nutr Neurosci. 2010 Jun;13(3):135–43. doi: 10.1179/147683010x12611460763968. X-120423563
391 Sheldrick RC, Perrin EC. Medical home services for children with behavioral health conditions. J Dev Behav Pediatr. 2010 Feb–Mar;31(2):92–9. doi: 10.1097/DBP.0b013e3181cdabda. X-120110825
392 Sheng L, Ding X, Ferguson M, . Prenatal polycyclic aromatic hydrocarbon exposure leads to behavioral deficits and downregulation of receptor tyrosine kinase, MET. Toxicol Sci. 2010 Dec;118(2):625–34. doi: 10.1093/toxsci/kfq304. X-120889680
393 Shute N. Desperate for an autism cure. Sci Am. 2010 Oct;303(4):80–5. X-1
394 Shyu YI, Tsai JL, Tsai WC. Explaining and selecting treatments for autism: parental explanatory models in Taiwan. J Autism Dev Disord. 2010 Nov;40(11):1323–31. doi: 10.1007/s10803-010-0991-1. X-1, X-420224997
395 Siegel B, Ihie E, Marco E, . Update on Autism. Psychiatric Times. 2010;27(10):33–9 7p. Language: English. Entry Date: 20110719. Revision Date: 20150712. Publication Type: Journal Article. X-1
396 Silverman JL, Tolu SS, Barkan CL, . Repetitive self-grooming behavior in the BTBR mouse model of autism is blocked by the mGluR5 antagonist MPEP. Neuropsychopharmacology. 2010 March;35(4):976–89. doi: http://dx.doi.org/10.1038/npp.2009.201. X-120032969
397 Smith IM, Koegel RL, Koegel LK, . Effectiveness of a novel community-based early intervention model for children with autistic spectrum disorder. Am J Intellect Dev Disabil. 2010 Nov;115(6):504–23. doi: 10.1352/1944-7558-115.6.504. X-1, X-320946003
398 Smyth C, Slevin E. Experiences of family life with an autism assistance dog. Learning Disability Practice. 2010;13(4):12–7 6p. Language: English. Entry Date: 20100625. Revision Date: 20150820. Publication Type: Journal Article. X-1, X-2
399 Sokhadze E, Baruth J, El-Baz A, . Impaired Error Monitoring and Correction Function in Autism. J Neurother. 2010 Apr 1;14(2):79–95. doi: 10.1080/10874201003771561. X-120523752
400 Sokhadze E, Baruth J, Tasman A, . Low-frequency repetitive transcranial magnetic stimulation (rTMS) affects event-related potential measures of novelty processing in autism. Appl Psychophysiol Biofeedback. 2010 Jun;35(2):147–61. doi: 10.1007/s10484-009-9121-2. X-3, X-419941058
401 Specchio N, Balestri M, Striano P, . Efficacy of levetiracetam in the treatment of drug-resistant Rett syndrome. Epilepsy Research. 2010 February;88(2–3):112–7. doi: http://dx.doi.org/10.1016/j.eplepsyres.2009.10.005. X-119914805
402 Sroka M, Regula J, Lobodziec W. The influence of the bolus-surface distance on the dose distribution in the build-up region. Rep Pract Oncol Radiother. 2010;15(6):161–4. doi: 10.1016/j.rpor.2010.09.003. X-124376943
403 St Pourcain B, Wang K, Glessner JT, . Association between a high-risk autism locus on 5p14 and social communication spectrum phenotypes in the general population. Am J Psychiatry. 2010 Nov;167(11):1364–72. doi: 10.1176/appi.ajp.2010.09121789. X-120634369
404 Staines R. School nurses can help identify children with undiagnosed autism. Paediatr Nurs. 2010 Mar;22(2):7. X-1
405 Staples K, Reid G. Fundamental movement skills and autism spectrum disorders. Journal of Autism & Developmental Disorders. 2010;40(2):209–17 9p. doi: 10.1007/s10803-009-0854-9. Language: English. Entry Date: 20100319. Revision Date: 20150711. Publication Type: Journal Article. X-119685284
406 Steward R. On the record: Robyn Steward. Interview by Alita Howe. Ment Health Today. 2010 Dec–2011 Jan:38. X-1, X-2
407 Stichter JP, Herzog MJ, Visovsky K, . Social competence intervention for youth with Asperger Syndrome and high-functioning autism: an initial investigation. J Autism Dev Disord. 2010 Sep;40(9):1067–79. doi: 10.1007/s10803-010-0959-1. X-1, X-320162344
408 Stieglitz Ham H, Bartolo A, Corley M, . Case report: Selective deficit in the production of intransitive gestures in an individual with autism. Cortex: A Journal Devoted to the Study of the Nervous System & Behavior. 2010;46(3):407–9 3p. doi: 10.1016/j.cortex.2009.06.005. Language: English. Entry Date: 20100514. Revision Date: 20150711. Publication Type: Journal Article. X-119615678
409 Stigler K, Wang Y, McDonald B, . Effects of aripiprazole on brain circuitry in youth with pervasive developmental disorders. Neuropsychopharmacology. 2010 December;35:S367. doi: http://dx.doi.org/10.1038/npp.2010.218. X-3, X-4
410 Stigler KA, Erickson CA, Mullett JE, . Paliperidone for irritability in autistic disorder. Journal of Child and Adolescent Psychopharmacology. 2010 01 Feb;20(1):75–8. doi: http://dx.doi.org/10.1089/cap.2009.0019. X-1, X-220166801
411 Su H, Dickstein-Fischer L, Harrington K, . Cable-driven elastic parallel humanoid head with face tracking for Autism Spectrum Disorder interventions. Conf Proc IEEE Eng Med Biol Soc. 2010;2010:467–70. doi: 10.1109/iembs.2010.5626186. X-121095653
412 Sung M, Fung DSS, Cai Y, . Pharmacological management in children and adolescents with pervasive developmental disorder. Australian & New Zealand Journal of Psychiatry. 2010;44(5):410–28 19p. doi: 10.3109/00048670903493330. Language: English. Entry Date: 20100521. Revision Date: 20150711. Publication Type: Journal Article. X-1, X-220047454
413 Sutherland A, Crewther DP. Magnocellular visual evoked potential delay with high autism spectrum quotient yields a neural mechanism for altered perception. Brain: A Journal of Neurology. 2010;133(7):2089–97 9p. doi: . Language: English. Entry Date: 20100806. Revision Date: 20150711. Publication Type: Journal Article. X-120513659
414 Tanaka JW, Wolf JM, Klaiman C, . Using computerized games to teach face recognition skills to children with autism spectrum disorder: the Let’s Face It! program. J Child Psychol Psychiatry. 2010 Aug;51(8):944–52. doi: 10.1111/j.1469-7610.2010.02258.x. X-120646129
415 Taurines R, Thome J, Duvigneau JC, . Expression analyses of the mitochondrial complex i 75-kDa subunit in early onset schizophrenia and autism spectrum disorder: Increased levels as a potential biomarker for early onset schizophrenia. European Child and Adolescent Psychiatry. 2010 May;19(5):441–8. doi: http://dx.doi.org/10.1007/s00787-009-0074-z. X-119894076
416 Taylor N, Isaac C, Milne E. A comparison of the development of audiovisual integration in children with autism spectrum disorders and typically developing children. J Autism Dev Disord. 2010 Nov;40(11):1403–11. doi: 10.1007/s10803-010-1000-4. X-120354776
417 Thiemann-Bourque KS. Instruction using the Picture Exchange Communication Systems (PECS) appears to enhance generalization of communication skills among children with autism in comparison to Responsive Education and Prelinguistic Milieu Teaching (RPMT). Evid Based Commun Assess Interv. 2010;4(4) doi: 10.1080/17489539.2011.554004. X-1
418 Thomas RH, Foley KA, Mepham JR, . Altered brain phospholipid and acylcarnitine profiles in propionic acid infused rodents: further development of a potential model of autism spectrum disorders. J Neurochem. 2010 Apr;113(2):515–29. X-120405543
419 Thompson L, Thompson M, Reid A. Neurofeedback outcomes in clients with Asperger’s syndrome. Appl Psychophysiol Biofeedback. 2010 Mar;35(1):63–81. doi: 10.1007/s10484-009-9120-3. X-1, X-2, X-319908142
420 Todd T, Reid G, Butler-Kisber L. Cycling for students with ASD: self-regulation promotes sustained physical activity. Adapt Phys Activ Q. 2010 Jul;27(3):226–41. X-1, X-3, X-420571157
421 Tom NC, Assinder SJ. Oxytocin: recent developments. Biomol Concepts. 2010 Dec 1;1(5–6):367–80. doi: 10.1515/bmc.2010.036. X-125962010
422 Torii M, Shimoyama I, Sugita K. Phonemic and semantic working memory in information processing in children with high function pervasive developmental disorders. International Medical Journal. 2010;17(1):35–9 5p. Language: English. Entry Date: 20100409. Revision Date: 20150711. Publication Type: Journal Article. X-1
423 Tsakanikos E, McCarthy J, Kravariti E, . The role of ethnicity in clinical psychopathology and care pathways of adults with intellectual disabilities. Res Dev Disabil. 2010 Mar–Apr;31(2):410–5. doi: 10.1016/j.ridd.2009.10.007. X-119932597
424 Tsiouris JA. Pharmacotherapy for aggressive behaviours in persons with intellectual disabilities: treatment or mistreatment? Journal of Intellectual Disability Research. 2010;54(1):1–16 p. doi: 10.1111/j.1365-2788.2009.01232.x. Language: English. Entry Date: 20100205. Revision Date: 20150711. Publication Type: Journal Article. X-1, X-2
425 Tsouderos T. Industrial chemical as autism treatment: the FDA hasn’t declared OSR#1 safe, but a company is selling it as a supplement for children anyway. Los Angeles Times -- Southern California Edition (Front Page). 2010:E1–E5 2p. Language: English. Entry Date: 20100312. Revision Date: 20150711. Publication Type: Journal Article. X-1, X-2
426 Tuchman R, Alessandri M, Cuccaro M. Autism spectrum disorders and epilepsy: Moving towards a comprehensive approach to treatment. Brain and Development. 2010 October;32(9):719–30. doi: http://dx.doi.org/10.1016/j.braindev.2010.05.007. X-1, x-220558021
427 Tunson J, Candler C. Behavioral States of children with severe disabilities in the multisensory environment. Phys Occup Ther Pediatr. 2010 May;30(2):101–10. doi: 10.3109/01942630903546651. X-120367515
428 Ulke-Kurkcuoglu B, Kircaali-Iftar G. A comparison of the effects of providing activity and material choice to children with autism spectrum disorders. J Appl Behav Anal. 2010 Winter;43(4):717–21. doi: 10.1901/jaba.2010.43-717. X-1, X-421541155
429 Umeda T, Takashima N, Nakagawa R, . Evaluation of pax6 mutant rat as a model for autism. PLoS ONE. 2010;5(12) doi: http://dx.doi.org/10.1371/journal.pone.0015500. X-1
430 Valdovinos MG, Bailey L, Taylor SL. Examining risperidone use in those diagnosed with autism 1 year after FDA approval. J Clin Psychiatry. 2010 May;71(5):651–2. doi: 10.4088/JCP.09l05665yel. X-220492856
431 Valenti M, Cerbo R, Masedu F, . Intensive intervention for children and adolescents with autism in a community setting in Italy: a single-group longitudinal study. Child Adolesc Psychiatry Ment Health. 2010;4:23. doi: 10.1186/1753-2000-4-23. X-320809976
432 Valentine K. A consideration of medicalisation: choice, engagement and other responsibilities of parents of children with autism spectrum disorder. Soc Sci Med. 2010 Sep;71(5):950–7. doi: 10.1016/j.socscimed.2010.06.010. X-120619521
433 van Haaren F. Risperidone and parent training in pervasive developmental disorders. J Am Acad Child Adolesc Psychiatry. 2010 Apr;49(4):406–7; author reply 7–8. X-1, X-220410733
434 Van Santen JP, Prud’hommeaux ET, Black LM, . Computational prosodic markers for autism. Autism: The International Journal of Research & Practice. 2010;14(3):215–36 22p. doi: 10.1177/1362361309363281. Language: English. Entry Date: 20100910. Revision Date: 20150711. Publication Type: Journal Article. X-120591942
435 Veenstra-Vanderweele J. Increase in valproic acid levels during riluzole treatment in an adolescent with autism. Journal of Child and Adolescent Psychopharmacology. 2010 01 Apr;20(2):163–5. doi: http://dx.doi.org/10.1089/cap.2009.0087. X-1, X-2, X-3, X-420415615
436 Vets TL, Green G. Three important things to consider when starting intervention for a child diagnosed with autism. Behav Anal Pract. 2010 Fall;3(2):56–7. X-122532896
437 Viau R, Arsenault-Lapierre G, Fecteau S, . Effect of service dogs on salivary cortisol secretion in autistic children. Psychoneuroendocrinology. 2010 Sep;35(8):1187–93. doi: 10.1016/j.psyneuen.2010.02.004. X-320189722
438 Villa S, Micheli E, Villa L, . Further empirical data on the psychoeducational profile-revised (PEP-R): reliability and validation with the Vineland adaptive behavior scales. J Autism Dev Disord. 2010 Mar;40(3):334–41. doi: 10.1007/s10803-009-0877-2. X-119777332
439 Villagonzalo KA, Dodd S, Dean O, . Oxidative pathways as a drug target for the treatment of autism. Expert Opinion on Therapeutic Targets. 2010 December;14(12):1301–10. doi: http://dx.doi.org/10.1517/14728222.2010.528394. X-1, X-220954799
440 Vlassopoulos M, Rotsika V, Mela L, . Increased frequency and service delivery for children with pervasive developmental disorders. Psychiatriki. 2010 Oct–Dec;21(4):294–303. X-121914612
441 Voelker R. FDA warning targets OTC chelation products. JAMA - Journal of the American Medical Association. 2010 17 Nov;304(19):2112. doi: http://dx.doi.org/10.1001/jama.2010.1654. X-121081718
442 Volden J, Phillips L. Measuring pragmatic language in speakers with autism spectrum disorders: Comparing the children’s communication checklist--2 and the test of pragmatic language. Am J Speech Lang Pathol. 2010 Aug;19(3):204–12. doi: 10.1044/1058-0360(2010/09-0011). X-120220047
443 Wachtel LE, Dhossche DM. Self-injury in autism as an alternate sign of catatonia: implications for electroconvulsive therapy. Med Hypotheses. 2010 Jul;75(1):111–4. doi: 10.1016/j.mehy.2010.02.001. X-1, X-2, X-320202760
444 Walker AN, Barry TD, Bader SH. Therapist and parent ratings of changes in adaptive social skills following a summer treatment camp for children with autism spectrum disorders: A preliminary study. Child & Youth Care Forum. 2010 2015-12-09;39(5):305–22. doi: http://dx.doi.org/10.1007/s10566-010-9110-x; 2010-20371-001. X-1, X-3
445 Wallace GL, Dankner N, Kenworthy L, . Age-related temporal and parietal cortical thinning in autism spectrum disorders. Brain. 2010 Dec;133(Pt 12):3745–54. doi: 10.1093/brain/awq279. X-120926367
446 Wallace S, Parsons S, Westbury A, . Sense of presence and atypical social judgments in immersive virtual environments. Responses of adolescents with Autism Spectrum Disorders. Autism. 2010 May;14(3):199–213. doi: 10.1177/1362361310363283. X-120484000
447 Wang L, Leslie DL. Health care expenditures for children with autism spectrum disorders in Medicaid. J Am Acad Child Adolesc Psychiatry. 2010 Nov;49(11):1165–71. doi: 10.1016/j.jaac.2010.08.003. X-120970704
448 Wang LW, Berry-Kravis E, Hagerman RJ. Fragile X: Leading the way for targeted treatments in autism. Neurotherapeutics. 2010 July;7(3):264–74. doi: http://dx.doi.org/10.1016/j.nurt.2010.05.005. X-120643379
449 Warren SF, Brady N, Sterling A, . Maternal responsivity predicts language development in young children with fragile X syndrome. Am J Intellect Dev Disabil. 2010 Jan;115(1):54–75. doi: 10.1352/1944-7558-115.1.54. X-120025359
450 Warren ZE, Sanders KB, Veenstra-Vanderweele J. Identity crisis involving body image in a young man with autism. American Journal of Psychiatry. 2010;167(11):1299–303 5p. doi: 10.1176/appi.ajp.2010.09091281. Language: English. Entry Date: 20110107. Revision Date: 20150711. Publication Type: Journal Article. X-121041252
451 Watson LR, Baranek GT, Roberts JE, . Behavioral and physiological responses to child-directed speech as predictors of communication outcomes in children with autism spectrum disorders. J Speech Lang Hear Res. 2010 Aug;53(4):1052–64. doi: 10.1044/1092-4388(2009/09-0096). X-120631229
452 Webb S. Drugmakers dance with autism. Nature Biotechnology. 2010 August;28(8):772–4. doi: http://dx.doi.org/10.1038/nbt0810-772. X-1
453 Wei R, Li Q, Chua SE, . Prenatal exposure to valproic acid induces a dose dependent impairment in sensorimotor gating in a mouse model of autism. International Journal of Neuropsychopharmacology. 2010 June;13:68. doi: http://dx.doi.org/10.1017/S1461145710000635. X-1
454 Weil TN, Inglehart MR. Dental education and dentists’ attitudes and behavior concerning patients with autism. J Dent Educ. 2010 Dec;74(12):1294–307. X-121123497
455 Weng SJ, Wiggins JL, Peltier SJ, . Alterations of resting state functional connectivity in the default network in adolescents with autism spectrum disorders. Brain Res. 2010 Feb 8;1313:202–14. doi: 10.1016/j.brainres.2009.11.057. X-120004180
456 Whalen C, Moss D, Ilan AB, . Efficacy of TeachTown: Basics computer-assisted intervention for the Intensive Comprehensive Autism Program in Los Angeles Unified School District. Autism. 2010 May;14(3):179–97. doi: 10.1177/1362361310363282. X-120484002
457 Wheelwright S, Auyeung B, Allison C, . Defining the broader, medium and narrow autism phenotype among parents using the Autism Spectrum Quotient (AQ). Mol Autism. 2010;1(1):10. doi: 10.1186/2040-2392-1-10. X-120678260
458 White SW, Albano AM, Johnson CR, . Development of a cognitive-behavioral intervention program to treat anxiety and social deficits in teens with high-functioning autism. Clin Child Fam Psychol Rev. 2010 Mar;13(1):77–90. doi: 10.1007/s10567-009-0062-3. X-120091348
459 Whiteley P, Haracopos D, Knivsberg AM, . The ScanBrit randomised, controlled, single-blind study of a gluten-and casein-free dietary intervention for children with autism spectrum disorders. Nutr Neurosci. 2010 Apr;13(2):87–100. doi: 10.1179/147683010x12611460763922.20406576
460 Wilder DA, Allison J, Nicholson K, . Further evaluation of antecedent interventions on compliance: the effects of rationales to increase compliance among preschoolers. J Appl Behav Anal. 2010 Winter;43(4):601–13. doi: 10.1901/jaba.2010.43-601. X-1, X-3, X-421541147
461 Williams K, Wheeler DM, Silove N, . Selective serotonin reuptake inhibitors (SSRIs) for autism spectrum disorders (ASD). Cochrane database of systematic reviews (Online). 2010;8:CD004677. X-2
462 Wimmer MC, Doherty MJ. Children with autism’s perception and understanding of ambiguous figures: evidence for pictorial metarepresentation, a research note. British Journal of Developmental Psychology. 2010;28(3):627–41 15p. doi: 10.1348/026151009X465362. Language: English. Entry Date: 20101012. Revision Date: 20150711. Publication Type: Journal Article. X-120849037
463 Wink LK, Erickson CA, McDougle CJ. Pharmacologic treatment of behavioral symptoms associated with autism and other pervasive developmental disorders. Curr Treat Options Neurol. 2010 Nov;12(6):529–38. doi: 10.1007/s11940-010-0091-8. X-2, X-3, X-420848330
464 Wink LK, Plawecki MH, Erickson CA, . Emerging drugs for the treatment of symptoms associated with autism spectrum disorders. Expert Opinion on Emerging Drugs. 2010 September;15(3):481–94. doi: http://dx.doi.org/10.1517/14728214.2010.487860. X-2, X-320470188
465 Wise MD, Little AA, Holliman JB, . Can state early intervention programs meet the increased demand of children suspected of having autism spectrum disorders? J Dev Behav Pediatr. 2010 Jul–Aug;31(6):469–76. doi: 10.1097/DBP.0b013e3181e56db2. X-120585267
466 Wong P. Selective mutism: a review of etiology, comorbidities, and treatment. Psychiatry (Edgmont). 2010 Mar;7(3):23–31. X-1
467 Wong VC, Chen WX. Randomized controlled trial of electro-acupuncture for autism spectrum disorder. Altern Med Rev. 2010 Jul;15(2):136–46. X-120806998
468 Wong VC, Kwan QK. Randomized controlled trial for early intervention for autism: a pilot study of the Autism 1–2–3 Project. J Autism Dev Disord. 2010 Jun;40(6):677–88. doi: 10.1007/s10803-009-0916-z. X-420020319
469 Wong VC, Sun JG. Randomized controlled trial of acupuncture versus sham acupuncture in autism spectrum disorder. J Altern Complement Med. 2010 May;16(5):545–53. doi: 10.1089/acm.2007.0768. X-120804366
470 Wu YW, Bi YP, Kou XX, . 17-Beta-estradiol enhanced allodynia of inflammatory temporomandibular joint through upregulation of hippocampal TRPV1 in ovariectomized rats. J Neurosci. 2010 Jun 30;30(26):8710–9. doi: 10.1523/jneurosci.6323-09.2010. X-120592193
471 Wuang YP, Wang CC, Huang MH, . The effectiveness of simulated developmental horse-riding program in children with autism. Adapt Phys Activ Q. 2010 Apr;27(2):113–26. X-120440023
472 Wynn T, Rawlings K. Sleepless in america: compounding with melatonin. Int J Pharm Compd. 2010 Jan–Feb;14(1):10. X-123965363
473 Yochum CL, Bhattacharya P, Patti L, . Animal model of autism using GSTM1 knockout mice and early post-natal sodium valproate treatment. Behav Brain Res. 2010 Jul 11;210(2):202–10. doi: 10.1016/j.bbr.2010.02.032. X-120178820
474 Yoder PJ, Lieberman RG. Brief Report: Randomized test of the efficacy of picture exchange communication system on highly generalized picture exchanges in children with ASD. J Autism Dev Disord. 2010 May;40(5):629–32. doi: 10.1007/s10803-009-0897-y. X-119904596
475 Yokotani K. Educational level signals unobserved abilities of people with high functioning autism spectrum disorders. Psychol Rep. 2010 Aug;107(1):227–35. doi: 10.2466/11.13.15.pr0.107.4.227-235. X-120923067
476 Zaidman-Zait A, Mirenda P, Zumbo BD, . An item response theory analysis of the Parenting Stress Index-Short Form with parents of children with autism spectrum disorders. J Child Psychol Psychiatry. 2010 Nov;51(11):1269–77. doi: 10.1111/j.1469-7610.2010.02266.x. X-120546082
477 Zappella M. Autistic regression with and without EEG abnormalities followed by favourable outcome. Brain and Development. 2010 October;32(9):739–45. doi: http://dx.doi.org/10.1016/j.braindev.2010.05.004. X-120708360
478 Zhang J. A review of Autism Spectrum Disorders (ASD) from a perspective of Classical Chinese Medicine (CCM). Journal of Traditional Chinese Medicine. 2010 March;30(1):53–9. X-120397465
479 No “magic pill” for autism spectrum disorders. Although medication prescriptions are common, there is little evidence they do any good. Harv Ment Health Lett. 2011 Aug;28(2):4. X-1
480 Autism spectrum disorders revisited. Several recent studies raise new questions about cause and prevention. Harv Ment Health Lett. 2011 Oct;28(4):1–3. x-1
481 Fear and its consequences. Sci Am. 2011 Feb;304(2):14. X-1
482 Motor training can advance social development in infants with autism. AACN Bold Voices. 2011;3(12):8- 1p. Language: English. Entry Date: 20120120. Revision Date: 20150712. Publication Type: Journal Article. X-1, X-2
483 DIGEST. Adapted Physical Activity Quarterly. 2011;28(2):176–9 4p. Language: English. Entry Date: 20110603. Revision Date: 20150711. Publication Type: Journal Article. Journal Subset: Allied Health. X-1, X-2
484 Autism and aquatics: activity manual for families. Journal of Aquatic Physical Therapy. 2011 2011 Spring;19(1):30- 1p. Language: English. Entry Date: 20120302. Revision Date: 20150712. Publication Type: Journal Article. X-1
485 Motor characteristics of young children with autism spectrum disorders are much lower than normal references. Pediatric Physical Therapy. 2011 2011 Spring;23(1):116- 1p. Language: English. Entry Date: 20110701. Revision Date: 20150712. Publication Type: Journal Article. X-1, X-2
486 A systematic review of motor impairments in children with autism spectrum disorder. Pediatric Physical Therapy. 2011 2011 Spring;23(1):132- 1p. Language: English. Entry Date: 20110701. Revision Date: 20150712. Publication Type: Journal Article. X-1, X-2
487 BRIEFLY NOTED. Mental Health Weekly. 2011;21(46):8- 1p. Language: English. Entry Date: 20131008. Revision Date: 20150710. Publication Type: Journal Article. X-1, X-2
488 Long-term risperidone effects on body weight in autism. Brown University Child & Adolescent Psychopharmacology Update. 2011;13(12):7- 1p. Language: English. Entry Date: 20130206. Revision Date: 20150711. Publication Type: Journal Article. X-1, X-2
489 Oculogyric crises induced by low-dose risperidone. Brown University Child & Adolescent Psychopharmacology Update. 2011;13(11):8- 1p. Language: English. Entry Date: 20111110. Revision Date: 20150711. Publication Type: Journal Article. X-1, X-2
490 Favorable atomoxetine response in autism and ADHD. Brown University Child & Adolescent Psychopharmacology Update. 2011;13(10):7–8 2p. Language: English. Entry Date: 20111005. Revision Date: 20150711. Publication Type: Journal Article. X-1, X-2
491 Aripiprazole safety and tolerability for irritability in autism. Brown University Child & Adolescent Psychopharmacology Update. 2011;13(9):4–5 2p. Language: English. Entry Date: 20110911. Revision Date: 20150711. Publication Type: Journal Article. Journal Subset: Biomedical. X-1, X-2
492 NEWS IN BRIEF. ASHA Leader. 2011;16(10):3- 1p. Language: English. Entry Date: 20110906. Revision Date: 20150712. Publication Type: Journal Article. X-1, X-2
493 Antidepressant use during pregnancy may have link to autism. Mental Health Weekly. 2011;21(32):3–4 2p. Language: English. Entry Date: 20110831. Revision Date: 20150711. Publication Type: Journal Article. Journal Subset: Biomedical. X-1, X-2
494 Patient-oriented evidence that matters: POEMs. JAAPA: Journal of the American Academy of Physician Assistants (Haymarket Media, Inc.). 2011;24(8):59–60 2p. Language: English. Entry Date: 20111014. Revision Date: 20150712. Publication Type: Journal Article. X-1, X-2
495 Product update. Journal of Psychosocial Nursing & Mental Health Services. 2011;49(6):5- 1p. doi: 10.3928/02793695-20110428-01. Language: English. Entry Date: 20110812. Revision Date: 20150711. Publication Type: Journal Article. X-1, X-2
496 Donepezil shows limited effect on cognitive functioning in autism. Brown University Child & Adolescent Psychopharmacology Update. 2011;13(4):1–3 p. doi: 10.1002/cpu.20137. Language: English. Entry Date: 20110713. Revision Date: 20150711. Publication Type: Journal Article. Journal Subset: Biomedical. X-1, X-2
497 Aripiprazole treatment of autistic disorder. Brown University Child & Adolescent Psychopharmacology Update. 2011;13(1):4–5 2p. Language: English. Entry Date: 20110713. Revision Date: 20150711. Publication Type: Journal Article. Journal Subset: Biomedical. X-1, X-2
498 Weight gain during aripiprazole treatment of irritability. Brown University Child & Adolescent Psychopharmacology Update. 2011;13(1):5–6 2p. Language: English. Entry Date: 20110713. Revision Date: 20150711. Publication Type: Journal Article. Journal Subset: Biomedical. X-1, X-2
499 Adamou M, Bowers S. Dose of Methylphenidate during Service Transition for Adults with ADHD. Ther Adv Psychopharmacol. 2011 Jun;1(3):71–5. doi: 10.1177/2045125311411603. X-123983928
500 Adams JB, Audhya T, McDonough-Means S, . Effect of a vitamin/mineral supplement on children and adults with autism. BMC Pediatr. 2011;11:111. doi: 10.1186/1471-2431-11-111. X-322151477
501 Adams JB, Audhya T, McDonough-Means S, . Nutritional and metabolic status of children with autism vs. neurotypical children, and the association with autism severity. Nutr Metab (Lond). 2011;8(1):34. doi: 10.1186/1743-7075-8-34. X-121651783
502 Adams JB, Johansen LJ, Powell LD, . Gastrointestinal flora and gastrointestinal status in children with autism--comparisons to typical children and correlation with autism severity. BMC Gastroenterol. 2011;11:22. doi: 10.1186/1471-230x-11-22. X-121410934
503 Ahrens EN, Lerman DC, Kodak T, . Further evaluation of response interruption and redirection as treatment for stereotypy. J Appl Behav Anal. 2011 Spring;44(1):95–108. doi: 10.1901/jaba.2011.44-95. X-3, X-421541130
504 Al Abdulmohsen T, Kruger TH. The contribution of muscular and auditory pathologies to the symptomatology of autism. Med Hypotheses. 2011 Dec;77(6):1038–47. doi: 10.1016/j.mehy.2011.08.044. X-1, X-2, X-3, X-421925796
505 Aldridge K, George ID, Cole KK, . Facial phenotypes in subgroups of prepubertal boys with autism spectrum disorders are correlated with clinical phenotypes. Mol Autism. 2011;2(1):15. doi: 10.1186/2040-2392-2-15. X-121999758
506 Amaral D, Rogers SJ, Baron-Cohen S, . Against le packing: a consensus statement. J Am Acad Child Adolesc Psychiatry. 2011 Feb;50(2):191–2. doi: 10.1016/j.jaac.2010.11.018. X-221241956
507 Amirabdollahian F, Robins B, Dautenhahn K, . Investigating tactile event recognition in child-robot interaction for use in autism therapy. Conf Proc IEEE Eng Med Biol Soc. 2011;2011:5347–51. doi: 10.1109/iembs.2011.6091323. X-1, X-2, X-322255546
508 Anagnostou E, Hansen R. Medical treatment overview: traditional and novel psycho-pharmacological and complementary and alternative medications. Current Opinion in Pediatrics. 2011;23(6):621–7 7p. Language: English. Entry Date: 20120127. Revision Date: 20150712. Publication Type: Journal Article. X-222001766
509 Andanson J, Pourre F, Maffre T, . [Social skills training groups for children and adolescents with Asperger syndrome: A review]. Arch Pediatr. 2011 May;18(5):589–96. doi: 10.1016/j.arcped.2011.02.019. X-1, X-2, X-321458972
510 Anderberg D, Chevalier A, Wadsworth J. Anatomy of a health scare: education, income and the MMR controversy in the UK. J Health Econ. 2011 May;30(3):515–30. doi: 10.1016/j.jhealeco.2011.01.009. X-121439663
511 Anderson-Hanley C, Tureck K, Schneiderman RL. Autism and exergaming: effects on repetitive behaviors and cognition. Psychol Res Behav Manag. 2011;4:129–37. doi: 10.2147/prbm.s24016. X-122114543
512 Antshel KM, Polacek C, McMahon M, . Comorbid ADHD and anxiety affect social skills group intervention treatment efficacy in children with autism spectrum disorders. J Dev Behav Pediatr. 2011 Jul–Aug;32(6):439–46. doi: 10.1097/DBP.0b013e318222355d. X-1, X-321654508
513 Asokan S, Ajit P. Mirror magic. Br Dent J. 2011 Jun;210(12):559. doi: 10.1038/sj.bdj.2011.491. X-1, X-221701456
514 Bagshaw M. Anaesthesia and the autistic child. J Perioper Pract. 2011 Sep;21(9):313–7. X-122474776
515 Bakare MO, Munir KM. Excess of non-verbal cases of autism spectrum disorders presenting to orthodox clinical practice in Africa - a trend possibly resulting from late diagnosis and intervention. S Afr J Psychiatr. 2011 Dec;17(4):118–20. X-122229024
516 Bakare MO, Munir KM, Kinney DK. Association of hypomelanotic skin disorders with autism: links to possible etiologic role of vitamin-D levels in autism? Hypothesis (Tor). 2011 Sep;9(1). X-1
517 Bakare MO, Munir KM, Kinney DK. Associations of hypomelanotic skin disorders with autism: Do they reflect the effects of genetic mutations and epigenetic factors on vitamin-D metabolism in individuals at risk for autism? Hypothesis (Macon). 2011 Apr 16;9(1):e2. X-125067901
518 Bakken TL. Review of My sensory book: Working together to explore sensory issues and the big feelings they can cause: A workbook for parents, professionals, and children. Journal of Autism and Developmental Disorders. 2011 2015-12-09;41(1):132–3. doi: http://dx.doi.org/10.1007/s10803-009-0934-x; 2010-26385-016. X-1, X-2, X-3
519 Bakouie F, Gharibzadeh S, Towhidkhah F. Does the “dynamic core” approach help to manage autistic behavioral disorders? J Neuropsychiatry Clin Neurosci. 2011 Summer;23(3):E1. doi: 10.1176/appi.neuropsych.23.3.E1. X-2
520 Bancroft SL, Weiss JS, Libby ME, . A comparison of procedural variations in teaching behavior chains: manual guidance, trainer completion, and no completion of untrained steps. J Appl Behav Anal. 2011 Fall;44(3):559–69. doi: 10.1901/jaba.2011.44-559. X-3, X-421941385
521 Banji D, Banji OJ, Abbagoni S, . Amelioration of behavioral aberrations and oxidative markers by green tea extract in valproate induced autism in animals. Brain Res. 2011 Sep 2;1410:141–51. doi: 10.1016/j.brainres.2011.06.063. X-121820650
522 Barbaro J, Ridgway L, Dissanayake C. Developmental surveillance of infants and toddlers by maternal and child health nurses in an Australian community-based setting: promoting the early identification of autism spectrum disorders. J Pediatr Nurs. 2011 Aug;26(4):334–47. doi: 10.1016/j.pedn.2010.04.007. X-121726784
523 Barnea-Goraly N, Hardan A. Advances in clinical neuroimaging: implications for autism spectrum disorders. Expert Opin Med Diagn. 2011 Nov;5(6):475–82. doi: 10.1517/17530059.2011.595785. X-123484746
524 Beherec L, Lambrey S, Quilici G, . Retrospective review of clozapine in the treatment of patients with autism spectrum disorder and severe disruptive behaviors. J Clin Psychopharmacol. 2011 Jun;31(3):341–4. doi: 10.1097/JCP.0b013e318218f4a1. X-1, X-321508854
525 Ben Said M, Robel L, Vion E, . Implementation and experimentation of TEDIS: an information system dedicated to patients with pervasive developmental disorders. Stud Health Technol Inform. 2011;169:270–4. X-121893755
526 Bendixen RM, Elder JH, Donaldson S, . Effects of a father-based in-home intervention on perceived stress and family dynamics in parents of children with autism. Am J Occup Ther. 2011 Nov–Dec;65(6):679–87. X-322214112
527 Bent S, Bertoglio K, Ashwood P, . A pilot randomized controlled trial of omega-3 fatty acids for autism spectrum disorder. J Autism Dev Disord. 2011 May;41(5):545–54. doi: 10.1007/s10803-010-1078-8.20683766
528 Benton TD. Aripiprazole to treat irritability associated with autism: a placebo-controlled, fixed-dose trial. Curr Psychiatry Rep. 2011 Apr;13(2):77–9. doi: 10.1007/s11920-010-0172-0. X-1, X-221286868
529 Berger BE, Navar-Boggan AM, Omer SB. Congenital rubella syndrome and autism spectrum disorder prevented by rubella vaccination--United States, 2001–2010. BMC Public Health. 2011;11:340. doi: 10.1186/1471-2458-11-340. X-121592401
530 Bernardi L, Tuzzi A. Analyzing written communication in AAC contexts: a statistical perspective. Augment Altern Commun. 2011 Sep;27(3):183–94. doi: 10.3109/07434618.2011.610353. X-122008031
531 Berry-Kravis E, Knox A, Hervey C. Targeted treatments for fragile X syndrome. J Neurodev Disord. 2011 Sep;3(3):193–210. doi: 10.1007/s11689-011-9074-7. X-121484200
532 Betz AM, Higbee TS, Kelley KN, . Increasing response variability of mand frames with script training and extinction. J Appl Behav Anal. 2011 Summer;44(2):357–62. doi: 10.1901/jaba.2011.44-357. X-3, X-421709793
533 Beversdorf DQ, Saklayen S, Higgins KF, . Effect of propranolol on word fluency in autism. Cogn Behav Neurol. 2011 Mar;24(1):11–7. doi: 10.1097/WNN.0b013e318204d20e. X-121487259
534 Bhandari A, Sandlow JI, Brannigan RE. Risks to offspring associated with advanced paternal age. J Androl. 2011 Mar–Apr;32(2):121–2. doi: 10.2164/jandrol.110.010595. X-120467047
535 Bhat AN, Landa RJ, Galloway JC. Current perspectives on motor functioning in infants, children, and adults with autism spectrum disorders. Phys Ther. 2011 Jul;91(7):1116–29. doi: 10.2522/ptj.20100294. X-121546566
536 Bishop DV, Jacobs PA, Lachlan K, . Autism, language and communication in children with sex chromosome trisomies. Arch Dis Child. 2011 Oct;96(10):954–9. doi: 10.1136/adc.2009.179747. X-120656736
537 Blaurock-Busch E, Amin OR, Rabah T. Heavy metals and trace elements in hair and urine of a sample of arab children with autistic spectrum disorder. Maedica (Buchar). 2011 Oct;6(4):247–57. X-122879836
538 Bolton PF, Carcani-Rathwell I, Hutton J, . Epilepsy in autism: features and correlates. Br J Psychiatry. 2011 Apr;198(4):289–94. doi: 10.1192/bjp.bp.109.076877. X-121972278
539 Bowker A, D’Angelo NM, Hicks R, . Treatments for autism: parental choices and perceptions of change. J Autism Dev Disord. 2011 Oct;41(10):1373–82. doi: 10.1007/s10803-010-1164-y. X-121161676
540 Boyd BA, McDonough SG, Rupp B, . Effects of a family-implemented treatment on the repetitive behaviors of children with autism. J Autism Dev Disord. 2011 Oct;41(10):1330–41. doi: 10.1007/s10803-010-1156-y. X-3, X-421161576
541 Boyd BA, Woodard CR, Bodfish JW. Modified exposure and response prevention to treat the repetitive behaviors of a child with autism: a case report. Case Rep Psychiatry. 2011;2011:241095. doi: 10.1155/2011/241095. X-1, X-3, X-422937399
542 Bragesjo F, Hallberg M. Dilemmas of a vitalizing vaccine market: lessons from the MMR vaccine/autism debate. Sci Context. 2011 Mar;24(1):107–25. X-121560548
543 Breslin CM, Rudisill ME. The Effect of Visual Supports on Performance of the TGMD-2 for Children With Autism Spectrum Disorder. Adapted Physical Activity Quarterly. 2011;28(4):342–53 12p. Language: English. Entry Date: 20111025. Revision Date: 20150819. Publication Type: Journal Article. X-121914906
544 Brown T. Right treatment, right patient? Am J Nurs. 2011 Jun;111(6):72. doi: 10.1097/01.NAJ.0000398546.90401.4b. X-1
545 Buckley AW, Sassower K, Rodriguez AJ, . An open label trial of donepezil for enhancement of rapid eye movement sleep in young children with autism spectrum disorders. J Child Adolesc Psychopharmacol. 2011 Aug;21(4):353–7. doi: 10.1089/cap.2010.0121. X-1, X-321851192
546 Burket JA, Herndon AL, Winebarger EE, . Complex effects of mGluR5 antagonism on sociability and stereotypic behaviors in mice: possible implications for the pharmacotherapy of autism spectrum disorders. Brain Res Bull. 2011 Oct 10;86(3–4):152–8. doi: 10.1016/j.brainresbull.2011.08.001. X-121840381
547 Calarge CA, Miller del D. Predictors of risperidone and 9-hydroxyrisperidone serum concentration in children and adolescents. J Child Adolesc Psychopharmacol. 2011 Apr;21(2):163–9. doi: 10.1089/cap.2010.0038. X-121486167
548 Call NA, Pabico RS, Findley AJ, . Differential reinforcement with and without blocking as treatment for elopement. J Appl Behav Anal. 2011 Winter;44(4):903–7. doi: 10.1901/jaba.2011.44-903. X-1, X-322219538
549 Cardon TA, Wilcox MJ. Promoting imitation in young children with autism: a comparison of reciprocal imitation training and video modeling. J Autism Dev Disord. 2011 May;41(5):654–66. doi: 10.1007/s10803-010-1086-8. X-3, X-420697791
550 Carter AS, Messinger DS, Stone WL, . A randomized controlled trial of Hanen’s ‘More Than Words’ in toddlers with early autism symptoms. J Child Psychol Psychiatry. 2011 Jul;52(7):741–52. doi: 10.1111/j.1469-7610.2011.02395.x. X-121418212
551 Cassella MD, Sidener TM, Sidener DW, . Response interruption and redirection for vocal stereotypy in children with autism: a systematic replication. J Appl Behav Anal. 2011 Spring;44(1):169–73. doi: 10.1901/jaba.2011.44-169. X-1, X-3, X-421541114
552 Casselyn M. [Early detection of autism: a questionnaire for parents. Interview with Hilary Wood]. Rev Med Suisse. 2011 Sep 14;7(308):1776. X-121954820
553 Castorina LL, Negri LM. The inclusion of siblings in social skills training groups for boys with Asperger syndrome. J Autism Dev Disord. 2011 Jan;41(1):73–81. doi: 10.1007/s10803-010-1023-x. X-120461452
554 Celik G, Tahiroglu AY, Firat S, . Aripiprazole Improved Obsessive Compulsive Symptoms in Asperger’s Disorder. Clin Psychopharmacol Neurosci. 2011 Dec;9(3):134–6. doi: 10.9758/cpn.2011.9.3.134. X-3, X-423429759
555 Cezar GG. Profile of Gabriela G. Cezar. Interview by Kristie Nybo. Biotechniques. 2011 May;50(5):281. doi: 10.2144/000113662. X-121548887
556 Chan AS, Sze SL, Cheung MC, . Dejian mind-body intervention improves the cognitive functions of a child with autism. Evid Based Complement Alternat Med. 2011;2011:549254. doi: 10.1155/2011/549254. X-121584249
557 Charles J, Harrison C, Britt H. Autism spectrum disorders. Aust Fam Physician. 2011 Sep;40(9):665. X-1, X-221894271
558 Charles J, Harrison CM, Britt H. Management of children’s psychological problems in general practice 1970–1971, 1990–1991 and 2008–2009. Australian & New Zealand Journal of Psychiatry. 2011;45(11):976–84 9p. doi: 10.3109/00048674.2011.610743. Language: English. Entry Date: 20111118. Revision Date: 20150711. Publication Type: Journal Article. X-122017686
559 Charnsil C. Efficacy of atomoxetine in children with severe autistic disorders and symptoms of ADHD: an open-label study. J Atten Disord. 2011 Nov;15(8):684–9. doi: 10.1177/1087054710376907. X-3, X-420686100
560 Chen B, Girgis S, Elmasry M, . Abnormal Gastrointestinal Histopathology in Children With Autism Spectrum Disorders. J Pediatr Gastroenterol Nutr. 2011 Feb 2 doi: 10.1097/MPG.0b013e3181f54f05. X-1
561 Chevallier C, Noveck I, Happe F, . What’s in a voice? Prosody as a test case for the Theory of Mind account of autism. Neuropsychologia. 2011 Feb;49(3):507–17. doi: 10.1016/j.neuropsychologia.2010.11.042. X-121134386
562 Chien IC, Lin CH, Chou YJ, . Prevalence and incidence of autism spectrum disorders among national health insurance enrollees in Taiwan from 1996 to 2005. J Child Neurol. 2011 Jul;26(7):830–4. doi: 10.1177/0883073810393964. X-121460178
563 Chow JC, Grigorov GN. Effect of the bone heterogeneity on the dose prescription in orthovoltage radiotherapy: A Monte Carlo study. Rep Pract Oncol Radiother. 2011;17(1):38–43. doi: 10.1016/j.rpor.2011.09.001. X-124376995
564 Chung SY, Yoon HJ. A framework for treatment of autism using affective computing. Stud Health Technol Inform. 2011;163:132–4. X-121335775
565 Chung TK, Lynch ER, Fiser CJ, . Psychiatric comorbidity and treatment response in patients with tuberous sclerosis complex. Ann Clin Psychiatry. 2011 Nov;23(4):263–9. X-122073383
566 Collins A, Dworkin RJ. Pilot study of the effectiveness of weighted vests. Am J Occup Ther. 2011 Nov–Dec;65(6):688–94. X-122214113
567 Corbett BA, Gunther JR, Comins D, . Brief report: theatre as therapy for children with autism spectrum disorder. J Autism Dev Disord. 2011 Apr;41(4):505–11. doi: 10.1007/s10803-010-1064-1. X-3, X-420640592
568 Cordeiro L, Ballinger E, Hagerman R, . Clinical assessment of DSM-IV anxiety disorders in fragile X syndrome: prevalence and characterization. J Neurodev Disord. 2011 Mar;3(1):57–67. doi: 10.1007/s11689-010-9067-y. X-121475730
569 Coulter ME, Miller DT, Harris DJ, . Chromosomal microarray testing influences medical management. Genet Med. 2011 Sep;13(9):770–6. doi: 10.1097/GIM.0b013e31821dd54a. X-121716121
570 Coury DL. [Commentary on] Review: little evidence of clear benefit for most medical treatments for children with autism spectrum disorders. Evidence Based Mental Health. 2011;14(4):105- 1p. doi: 10.1136/ebmh.2011.100112. Language: English. Entry Date: 20111116. Revision Date: 20150711. Publication Type: Journal Article. X-1, X-221963708
571 Crighton P. Vaccines need a shot in the arm. Aust Nurs J. 2011 May;18(10):40–1. X-1
572 Critchfield JW, van Hemert S, Ash M, . The potential role of probiotics in the management of childhood autism spectrum disorders. Gastroenterol Res Pract. 2011;2011:161358. doi: 10.1155/2011/161358. X-122114588
573 Croen LA, Grether JK, Yoshida CK, . Antidepressant use during pregnancy and childhood autism spectrum disorders. Arch Gen Psychiatry. 2011 Nov;68(11):1104–12. doi: 10.1001/archgenpsychiatry.2011.73. X-121727247
574 Cukier SH, Wahlberg E. [Autism spectrum disorders. Functional-emotional development hypotheses and their relationship with therapeutic interventions]. Vertex. 2011 Mar–Apr;22(96):135–46. X-121977608
575 Curran MP. Aripiprazole in the treatment of irritability associated with autistic disorder in paediatric patients: profile report. CNS Drugs. 2011 Sep 1;25(9):801–2. doi: 10.2165/11208280-000000000-00000. X-2, X-321870890
576 Daley MF, Glanz JM. Straight talk about vaccination. Sci Am. 2011 Sep;305(3):32, 4. X-1
577 Dardennes RM, Al Anbar NN, Prado-Netto A, . Treating the cause of illness rather than the symptoms: parental causal beliefs and treatment choices in autism spectrum disorder. Res Dev Disabil. 2011 May–Jun;32(3):1137–46. doi: 10.1016/j.ridd.2011.01.010. X-121316189
578 David N, Schneider TR, Vogeley K, . Impairments in multisensory processing are not universal to the autism spectrum: No evidence for crossmodal priming deficits in Asperger syndrome. Autism Research. 2011 2015-12-09;4(5):383–8. doi: 10.1007/s10803-010-1000-4 http://dx.doi.org/10.1002/aur.210; 2011-23487-007. X-121882310
579 David N, T RS, Vogeley K, . Impairments in multisensory processing are not universal to the autism spectrum: no evidence for crossmodal priming deficits in Asperger syndrome. Autism Res. 2011 Oct;4(5):383–8. doi: 10.1002/aur.210. X-121882310
580 Davis TN, Durand S, Chan JM. The effects of a brushing procedure on stereotypical behavior. Research in Autism Spectrum Disorders. 2011 2015-02-24;5(3):1053–8. doi: http://dx.doi.org/10.1016/j.rasd.2010.11.011; 2011-04787-013. X-3, X-4
581 Davit CJ, Hundley RJ, Bacic JD, . A pilot study to improve venipuncture compliance in children and adolescents with autism spectrum disorders. J Dev Behav Pediatr. 2011 Sep;32(7):521–5. doi: 10.1097/DBP.0b013e3182245b09. X-1, X-321694630
582 De Leo G, Gonzales CH, Battagiri P, . A smart-phone application and a companion website for the improvement of the communication skills of children with autism: clinical rationale, technical development and preliminary results. J Med Syst. 2011 Aug;35(4):703–11. doi: 10.1007/s10916-009-9407-1. X-1, X-220703781
583 Defensor EB, Pearson BL, Pobbe RL, . A novel social proximity test suggests patterns of social avoidance and gaze aversion-like behavior in BTBR T+ tf/J mice. Behav Brain Res. 2011 Mar 1;217(2):302–8. doi: 10.1016/j.bbr.2010.10.033. X-121055421
584 Delong G. A positive association found between autism prevalence and childhood vaccination uptake across the U.S. population. J Toxicol Environ Health A. 2011;74(14):903–16. doi: 10.1080/15287394.2011.573736. X-121623535
585 Demb H, Valicenti-McDermott M, Navarro A, . The effect of long-term use of risperidone on body weight of children with an autism spectrum disorder. J Clin Psychopharmacol. 2011 Oct;31(5):669–70. doi: 10.1097/JCP.0b013e31822befa9. X-221881456
586 DeRosier ME, Swick DC, Davis NO, . The efficacy of a Social Skills Group Intervention for improving social behaviors in children with High Functioning Autism Spectrum disorders. J Autism Dev Disord. 2011 Aug;41(8):1033–43. doi: 10.1007/s10803-010-1128-2. X-121042870
587 Devlin S, Healy O, Leader G, . Comparison of behavioral intervention and sensory-integration therapy in the treatment of challenging behavior. J Autism Dev Disord. 2011 Oct;41(10):1303–20. doi: 10.1007/s10803-010-1149-x. X-421161577
588 Dickstein-Fischer L, Alexander E, Yan X, . An affordable compact humanoid robot for Autism Spectrum Disorder interventions in children. Conf Proc IEEE Eng Med Biol Soc. 2011;2011:5319–22. doi: 10.1109/iembs.2011.6091316. X-122255539
589 DiGennaro Reed FD, Reed DD, Baez CN, . A parametric analysis of errors of commission during discrete-trial training. J Appl Behav Anal. 2011 Fall;44(3):611–5. doi: 10.1901/jaba.2011.44-611. X-1, X-421941391
590 Dingfelder HE, Mandell DS. Bridging the research-to-practice gap in autism intervention: an application of diffusion of innovation theory. J Autism Dev Disord. 2011 May;41(5):597–609. doi: 10.1007/s10803-010-1081-0. X-1, X-2, X-320717714
591 Dittlinger LH, Lerman DC. Further analysis of picture interference when teaching word recognition to children with autism. J Appl Behav Anal. 2011 Summer;44(2):341–9. doi: 10.1901/jaba.2011.44-341. X-121709789
592 Dodds L, Fell DB, Shea S, . The role of prenatal, obstetric and neonatal factors in the development of autism. J Autism Dev Disord. 2011 Jul;41(7):891–902. doi: 10.1007/s10803-010-1114-8. X-120922473
593 Donaldson SO, Elder JH, Self EH, . Fathers’ perceptions of their roles during in-home training for children with autism. J Child Adolesc Psychiatr Nurs. 2011 Nov;24(4):200–7. doi: 10.1111/j.1744-6171.2011.00300.x. X-1, X-3, X-422044567
594 Donnachie P. CHILDREN BEHAVING BADLY. Health & Homeopathy. 2011:9–11 3p. Language: English. Entry Date: 20120810. Revision Date: 20150711. Publication Type: Journal Article. X-1
595 Donoghue K, Stallard P, Kucia J. The clinical practice of Cognitive Behavioural Therapy for children and young people with a diagnosis of Asperger’s Syndrome. Clin Child Psychol Psychiatry. 2011 Jan;16(1):89–102. doi: 10.1177/1359104509355019. X-120516059
596 Doty KJ. Student perceptions of progress in a postsecondary residential program for adults with learning disabilities. J Soc Work Disabil Rehabil. 2011;10(3):150–65. doi: 10.1080/1536710x.2011.596431. X-121827300
597 Doughty AH, Hopkins MN. Reducing stimulus overselectivity through an increased observing-response requirement. J Appl Behav Anal. 2011 Fall;44(3):653–7. doi: 10.1901/jaba.2011.44-653. X-121941399
598 Douglas-Hall P, Curran S, Bird V, . Aripiprazole: a review of its use in the treatment of irritability associated with autistic disorder patients aged 6–17. J Cent Nerv Syst Dis. 2011;3:143–53. doi: 10.4137/jcnsd.s4140. X-223861644
599 Dowben JS, Grant JS, Keltner NL. Clonidine: Diverse Use in Pharmacologic Management. Perspectives in Psychiatric Care. 2011;47(2):105–8 4p. doi: 10.1111/j.1744-6163.2011.00302.x. Language: English. Entry Date: 20110330. Revision Date: 20150818. Publication Type: Journal Article. X-1, X-221426356
600 Drahota A, Wood JJ, Sze KM, . Effects of cognitive behavioral therapy on daily living skills in children with high-functioning autism and concurrent anxiety disorders. J Autism Dev Disord. 2011 Mar;41(3):257–65. doi: 10.1007/s10803-010-1037-4. X-120508979
601 Dunst CJ, Trivette CM, Masiello T. Exploratory investigation of the effects of interest-based learning on the development of young children with autism. Autism. 2011 May;15(3):295–305. doi: 10.1177/1362361310370971. X-3, X-421430019
602 Dykens EM, Lee E, Roof E. Prader-Willi syndrome and autism spectrum disorders: an evolving story. J Neurodev Disord. 2011 Sep;3(3):225–37. doi: 10.1007/s11689-011-9092-5. X-121858456
603 Edrisinha C, O’Reilly MF, Choi HY, . “Say Cheese”: teaching photography skills to adults with developmental disabilities. Res Dev Disabil. 2011 Mar–Apr;32(2):636–42. doi: 10.1016/j.ridd.2010.12.006. X-121227636
604 Ekas NV, Whitman TL. Adaptation to daily stress among mothers of children with an autism spectrum disorder: the role of daily positive affect. J Autism Dev Disord. 2011 Sep;41(9):1202–13. doi: 10.1007/s10803-010-1142-4. X-121125322
605 Erdmann J. Broad collaborations bring new energy to autism therapeutics. Chem Biol. 2011 Feb 25;18(2):142–3. doi: 10.1016/j.chembiol.2011.02.006. X-1, X-2, X-321338911
606 Erickson CA, Early M, Stigler KA, . An open-label naturalistic pilot study of acamprosate in youth with autistic disorder. J Child Adolesc Psychopharmacol. 2011 Dec;21(6):565–9. doi: 10.1089/cap.2011.0034. X-3, X-422136091
607 Erickson CA, Weng N, Weiler IJ, . Open-label riluzole in fragile X syndrome. Brain Res. 2011 Mar 22;1380:264–70. doi: 10.1016/j.brainres.2010.10.108. X-121059347
608 Esposito G, Venuti P, Bornstein MH. ASSESSMENT OF DISTRESS IN YOUNG CHILDREN: A COMPARISON OF AUTISTIC DISORDER, DEVELOPMENTAL DELAY, AND TYPICAL DEVELOPMENT. Res Autism Spectr Disord. 2011;5(4):1510–6. doi: 10.1016/j.rasd.2011.02.013. X-1, X-321647245
609 Estigarribia B, Martin GE, Roberts JE, . Narrative Skill in Boys with Fragile X Syndrome with and without Autism Spectrum Disorder. Appl Psycholinguist. 2011;32(2):359–88. doi: 10.1017/s0142716410000445. X-121516264
610 Farmer CA, Aman MG. Aripiprazole for the treatment of irritability associated with autism. Expert Opin Pharmacother. 2011 Mar;12(4):635–40. doi: 10.1517/14656566.2011.557661. X-2, X-3, X-421294670
611 Farook S, Subudhi C, Syed A. MINERVA. BMJ: British Medical Journal (Overseas & Retired Doctors Edition). 2011;343(7824):646- 1p. Language: English. Entry Date: 20111108. Revision Date: 20150711. Publication Type: Journal Article. X-1
612 Fecteau S, Agosta S, Oberman L, . Brain stimulation over Broca’s area differentially modulates naming skills in neurotypical adults and individuals with Asperger’s syndrome. Eur J Neurosci. 2011 Jul;34(1):158–64. doi: 10.1111/j.1460-9568.2011.07726.x. X-121676037
613 Fernandes FD, Amato CA, Balestro JI, . Orientation to mothers of children of the autistic spectrum about language and communication. J Soc Bras Fonoaudiol. 2011 Mar;23(1):1–7. X-1
614 Fernell E, Hedvall A, Westerlund J, . Early intervention in 208 Swedish preschoolers with autism spectrum disorder. A prospective naturalistic study. Res Dev Disabil. 2011 Nov–Dec;32(6):2092–101. doi: 10.1016/j.ridd.2011.08.002. X-121985993
615 Ferreri SJ, Plavnick JB. A functional analysis of gestural behaviors emitted by young children with severe developmental disabilities. Anal Verbal Behav. 2011;27(1):185–90. X-122532763
616 Finegold SM. State of the art; microbiology in health and disease. Intestinal bacterial flora in autism. Anaerobe. 2011 Dec;17(6):367–8. doi: 10.1016/j.anaerobe.2011.03.007. X-121524713
617 Fitzpatrick M. Warehousing. Br J Gen Pract. 2011 Jul;61(588):466. doi: 10.3399/bjgp11X583443. X-2, X-321722473
618 Flores CG, Valcante G, Guter S, . Repetitive behavior profiles: Consistency across autism spectrum disorder cohorts and divergence from Prader-Willi syndrome. J Neurodev Disord. 2011 Dec;3(4):316–24. doi: 10.1007/s11689-011-9094-3. X-121881965
619 Fong SS, Lee VY, Chan NN, . Motor ability and weight status are determinants of out-of-school activity participation for children with developmental coordination disorder. Res Dev Disabil. 2011 Nov–Dec;32(6):2614–23. doi: 10.1016/j.ridd.2011.06.013. X-121767931
620 Fragala-Pinkham MA, Haley SM, O’Neil ME. Group swimming and aquatic exercise programme for children with autism spectrum disorders: a pilot study. Dev Neurorehabil. 2011;14(4):230–41. doi: 10.3109/17518423.2011.575438. X-421732807
621 Frazier TW, Shattuck PT, Narendorf SC, . Prevalence and correlates of psychotropic medication use in adolescents with an autism spectrum disorder with and without caregiver-reported attention-deficit/hyperactivity disorder. J Child Adolesc Psychopharmacol. 2011 Dec;21(6):571–9. doi: 10.1089/cap.2011.0057. X-122166171
622 Freed J, Adams C, Lockton E. Literacy skills in primary school-aged children with pragmatic language impairment: a comparison with children with specific language impairment. Int J Lang Commun Disord. 2011 May–Jun;46(3):334–47. doi: 10.3109/13682822.2010.500316. X-121575074
623 Freitag C, Herpertz-Dahlmann B, Dose M, . [Statement on a letter by <<Pyramid Educational Consultants Germany UG>> of May 2010]. Z Kinder Jugendpsychiatr Psychother. 2011 Nov;39(6):417–9. doi: 10.1024/1422-4917/a000140. X-122031014
624 Froehlich W. Making a case to continue considering treatment with selective serotonin reuptake inhibitors for children with autism spectrum disorders. Curr Psychiatry Rep. 2011 Jun;13(3):170–3. doi: 10.1007/s11920-011-0196-0. X-1, X-221404127
625 Frye RE, Sreenivasula S, Adams JB. Traditional and non-traditional treatments for autism spectrum disorder with seizures: an on-line survey. BMC Pediatr. 2011;11:37. doi: 10.1186/1471-2431-11-37. X-121592359
626 Fuentes C, Mostofsky S, Bastian A. No Proprioceptive Deficits in Autism Despite Movement-Related Sensory and Execution Impairments. Journal of Autism & Developmental Disorders. 2011;41(10):1352–61 10p. doi: 10.1007/s10803-010-1161-1. Language: English. Entry Date: 20110930. Revision Date: 20150711. Publication Type: Journal Article. X-121165765
627 Gadberry AL. A survey of the use of aided augmentative and alternative communication during music therapy sessions with persons with autism spectrum disorders. J Music Ther. 2011 Spring;48(1):74–89. X-121866714
628 Gale CM, Eikeseth S, Rudrud E. Functional assessment and behavioural intervention for eating difficulties in children with autism: a study conducted in the natural environment using parents and ABA tutors as therapists. J Autism Dev Disord. 2011 Oct;41(10):1383–96. doi: 10.1007/s10803-010-1167-8. X-3, X-421181250
629 Gallup GG, Jr., Hobbs DR. Evolutionary medicine: bottle feeding, birth spacing, and autism. Med Hypotheses. 2011 Sep;77(3):345–6. doi: 10.1016/j.mehy.2011.05.010. X-121641730
630 Gargaro BA, Rinehart NJ, Bradshaw JL, . Autism and ADHD: how far have we come in the comorbidity debate? Neurosci Biobehav Rev. 2011 Apr;35(5):1081–8. doi: 10.1016/j.neubiorev.2010.11.002. X-121093480
631 Gastgeb H, Wilkinson D, Minshew N, . Can Individuals with Autism Abstract Prototypes of Natural Faces? Journal of Autism & Developmental Disorders. 2011;41(12):1609–18 10p. doi: 10.1007/s10803-011-1190-4. Language: English. Entry Date: 20111212. Revision Date: 20150711. Publication Type: Journal Article. X-121318641
632 Gawronski A, Kuzmanovic B, Georgescu A, . [Expectations concerning psychotherapy of high-functioning adults with autism spectrum disorders]. Fortschr Neurol Psychiatr. 2011 Nov;79(11):647–54. doi: 10.1055/s-0031-1281734. X-122006206
633 Geier DA, Kern JK, Davis G, . A prospective double-blind, randomized clinical trial of levocarnitine to treat autism spectrum disorders. Med Sci Monit. 2011 Jun;17(6):Pi15–23.21629200
634 Gerber F, Bessero S, Robbiani B, . Comparing residential programmes for adults with autism spectrum disorders and intellectual disability: outcomes of challenging behaviour and quality of life. J Intellect Disabil Res. 2011 Sep;55(9):918–32. doi: 10.1111/j.1365-2788.2011.01455.x. X-121806693
635 Gerdts J, Bernier R. The broader autism phenotype and its implications on the etiology and treatment of autism spectrum disorders. Autism Res Treat. 2011;2011:545901. doi: 10.1155/2011/545901. X-122937250
636 Ghanizadeh A. c-Kit+ cells transplantation as a new treatment for autism, a novel hypothesis with important research and clinical implication. J Autism Dev Disord. 2011 Nov;41(11):1591–2. doi: 10.1007/s10803-010-1174-9. X-221225454
637 Ghanizadeh A. Targeting of glycine site on NMDA receptor as a possible new strategy for autism treatment. Neurochem Res. 2011 May;36(5):922–3. doi: 10.1007/s11064-010-0381-2. X-1, X-2, X-321210221
638 Ghanizadeh A. May lovastatin target both autism and epilepsy? A novel hypothesized treatment. Epilepsy Behav. 2011 Feb;20(2):422. doi: 10.1016/j.yebeh.2010.12.027. X-221269887
639 Ghanizadeh A. Can ziconotide as a N-type voltage-sensitive calcium channel blocker open a new mode for treatment of autism? A hypothesis. Neurosciences (Riyadh). 2011 Jan;16(1):83. X-1, X-221206454
640 Ghanizadeh A. Gold implants and increased expression of metallothionein-I/II as a novel hypothesized therapeutic approach for autism. Toxicology. 2011 Apr 28;283(1):63–4. doi: 10.1016/j.tox.2011.02.002. X-221335051
641 Ghanizadeh A. Ghrelin as a promising therapeutic target for co-occurring autism and epilepsy. Epilepsy Behav. 2011 Feb;20(2):420–1. doi: 10.1016/j.yebeh.2010.12.009. X-121220213
642 Ghanizadeh A. Can tactile sensory processing differentiate between children with autistic disorder and asperger’s disorder? Innov Clin Neurosci. 2011 May;8(5):25–30. X-1
643 Ghanizadeh A. A novel hypothesized clinical implication of zonisamide for autism…Ann Neurol. 2010 Feb;67(2):239–49. Annals of Neurology. 2011;69(2):426- 1p. doi: 10.1002/ana.22153. Language: English. Entry Date: 20110527. Revision Date: 20150711. Publication Type: Journal Article. X-1, X-221387391
644 Ghoneim OM, Ibrahim DA, El-Deeb IM, . A novel potential therapeutic avenue for autism: design, synthesis and pharmacophore generation of SSRIs with dual action. Bioorg Med Chem Lett. 2011 Nov 15;21(22):6714–23. doi: 10.1016/j.bmcl.2011.09.046. X-121982496
645 Gibbs V, Toth-Cohen S. Family-centered occupational therapy and telerehabilitation for children with autism spectrum disorders. Occup Ther Health Care. 2011 Oct;25(4):298–314. doi: 10.3109/07380577.2011.606460. X-1, X-3, X-423899082
646 Gillesen JC, Barakova EI, Huskens BE, . From training to robot behavior: towards custom scenarios for robotics in training programs for ASD. IEEE Int Conf Rehabil Robot. 2011;2011:5975381. doi: 10.1109/icorr.2011.5975381. X-122275585
647 Golubchik P, Sever J, Weizman A. Low-dose quetiapine for adolescents with autistic spectrum disorder and aggressive behavior: open-label trial. Clin Neuropharmacol. 2011 Nov–Dec;34(6):216–9. doi: 10.1097/WNF.0b013e31823349ac. X-121996644
648 Gomot M, Blanc R, Clery H, . Candidate electrophysiological endophenotypes of hyper-reactivity to change in autism. J Autism Dev Disord. 2011 Jun;41(6):705–14. doi: 10.1007/s10803-010-1091-y. X-120827502
649 Gooding LF. The effect of a music therapy social skills training program on improving social competence in children and adolescents with social skills deficits. J Music Ther. 2011 Winter;48(4):440–62. X-1, X-3, X-422506299
650 Gordon K, Pasco G, McElduff F, . A communication-based intervention for nonverbal children with autism: what changes? Who benefits? J Consult Clin Psychol. 2011 Aug;79(4):447–57. doi: 10.1037/a0024379. X-121787048
651 Gray K, Jenkins AC, Heberlein AS, . Distortions of mind perception in psychopathology. Proc Natl Acad Sci U S A. 2011 Jan 11;108(2):477–9. doi: 10.1073/pnas.1015493108. X-121187372
652 Greco CM, Navarro CS, Hunsaker MR, . Neuropathologic features in the hippocampus and cerebellum of three older men with fragile X syndrome. Mol Autism. 2011;2(1):2. doi: 10.1186/2040-2392-2-2. X-121303513
653 Greer RD, Pistoljevic N, Cahill C, . Effects of conditioning voices as reinforcers for listener responses on rate of learning, awareness, and preferences for listening to stories in preschoolers with autism. Anal Verbal Behav. 2011;27(1):103–24. X-1, X-3, X-422532758
654 Griffith GM, Hastings RP, Oliver C, . Psychological well-being in parents of children with Angelman, Cornelia de Lange and Cri du Chat syndromes. J Intellect Disabil Res. 2011 Apr;55(4):397–410. doi: 10.1111/j.1365-2788.2011.01386.x. X-121323782
655 Grow LL, Carr JE, Kodak TM, . A comparison of methods for teaching receptive labeling to children with autism spectrum disorders. J Appl Behav Anal. 2011 Fall;44(3):475–98. doi: 10.1901/jaba.2011.44-475. X-3, X-421941380
656 Guénolé F, Baleyte J-M. Melatonin for sleep-disturbed children with autism spectrum disorders: can we really speak of a substitution treatment? European Child & Adolescent Psychiatry. 2011;20(9):493–4 2p. doi: 10.1007/s00787-011-0196-y. Language: English. Entry Date: 20111004. Revision Date: 20150711. Publication Type: Journal Article. X-1, X-221713505
657 Guerra DJ. The molecular genetics of autism spectrum disorders: genomic mechanisms, neuroimmunopathology, and clinical implications. Autism Res Treat. 2011;2011:398636. doi: 10.1155/2011/398636. X-122937247
658 Guex P, Halfon O. [Hegemonic model of autism: epistemological crossroads between medicine, family and politics]. Rev Med Suisse. 2011 Sep 21;7(309):1813–6. X-122016936
659 Guiraud JA, Kushnerenko E, Tomalski P, . Differential habituation to repeated sounds in infants at high risk for autism. Neuroreport. 2011 Nov 16;22(16):845–9. doi: 10.1097/WNR.0b013e32834c0bec. X-121934535
660 Hall HR, Graff JC. The relationships among adaptive behaviors of children with autism, family support, parenting stress, and coping. Issues Compr Pediatr Nurs. 2011;34(1):4–25. doi: 10.3109/01460862.2011.555270. X-121341964
661 Ham HS, Bartolo A, Corley M, . Exploring the relationship between gestural recognition and imitation: evidence of dyspraxia in autism spectrum disorders. Journal of Autism & Developmental Disorders. 2011;41(1):1–12 p. doi: 10.1007/s10803-010-1011-1. Language: English. Entry Date: 20110228. Revision Date: 20150711. Publication Type: Journal Article. X-120407815
662 Hameury L, Delavous P, Leroy C. [Hippotherapy in the paedopsychiatric care project]. Soins Pediatr Pueric. 2011 Jan–Feb(258):37–40. X-1, X-3
663 Hamilton A, Marshal MP, Murray PJ. Autism spectrum disorders and menstruation. J Adolesc Health. 2011 Oct;49(4):443–5. doi: 10.1016/j.jadohealth.2011.01.015. X-121939879
664 Hampson DR, Adusei DC, Pacey LK. The neurochemical basis for the treatment of autism spectrum disorders and Fragile X Syndrome. Biochem Pharmacol. 2011 May 1;81(9):1078–86. doi: 10.1016/j.bcp.2011.02.005. X-121333634
665 Handen BL, Johnson CR, McAuliffe-Bellin S, . Safety and efficacy of donepezil in children and adolescents with autism: neuropsychological measures. J Child Adolesc Psychopharmacol. 2011 Feb;21(1):43–50. doi: 10.1089/cap.2010.0024.21309696
666 Hayakawa K, Kobayashi K. Physical and motor skill training for children with intellectual disabilities. Percept Mot Skills. 2011 Apr;112(2):573–80. doi: 10.2466/06.13.15.pms.112.2.573-580. X-121667765
667 Healy O, Hughes B, Leader G, . Response to a Letter to the Editors re: ‘Comparison of Behavioral Intervention and Sensory-Integration Therapy in the Treatment of Challenging Behavior’…Devlin, S., Healy, O., Leader, G., & Hughes, B. M. (2010). Journal of Autism and Developmental Disorders, 1–18. doi:10.1007/s10803-010-1149-x. Journal of Autism & Developmental Disorders. 2011;41(10):1439–41 3p. doi: 10.1007/s10803-011-1295-9. Language: English. Entry Date: 20110930. Revision Date: 20150711. Publication Type: Journal Article. X-1, X-2
668 Hellings JA, Boehm D, Yeh HW, . Long-term aripiprazole in youth with developmental disabilities including autism. Journal of Mental Health Research in Intellectual Disabilities. 2011 2015-12-09;4(1):40–52. doi: http://dx.doi.org/10.1080/19315864.2010.542274; 2011-05041-003. X-1, X-328163818
669 Hepburn SL, Moody EJ. Diagnosing Autism in Individuals with Known Genetic Syndromes: Clinical Considerations and Implications for Intervention. Int Rev Res Dev Disabil. 2011;40:229–59. doi: 10.1016/b978-0-12-374478-4.00009-5. X-126269783
670 Hernandez P, Ikkanda Z. Applied behavior analysis: behavior management of children with autism spectrum disorders in dental environments. J Am Dent Assoc. 2011 Mar;142(3):281–7. X-121357862
671 Hines M, Balandin S, Togher L. Communication and AAC in the lives of adults with autism: the stories of their older parents. Augment Altern Commun. 2011 Dec;27(4):256–66. doi: 10.3109/07434618.2011.587830. X-122136364
672 Hodgetts S, Magill-Evans J, Misiaszek J. Effects of weighted vests on classroom behavior for children with autism and cognitive impairments. Research in Autism Spectrum Disorders. 2011 2015-12-09;5(1):495–505. doi: 10.1016/j.rasd.2006.08.006 http://dx.doi.org/10.1016/j.rasd.2010.06.015; 2010-22960-053. X-1, X-3
673 Hodgetts S, Magill-Evans J, Misiaszek JE. Weighted vests, stereotyped behaviors and arousal in children with autism. J Autism Dev Disord. 2011 Jun;41(6):805–14. doi: 10.1007/s10803-010-1104-x. X-3, X-420839040
674 Hodgson ES, McGonigle-Chalmers M. Partial occlusion depiction and its relationship with field independence in children with ASD. Autism: The International Journal of Research & Practice. 2011;15(4):473–95 23p. doi: 10.1177/1362361310363279. Language: English. Entry Date: 20110901. Revision Date: 20150711. Publication Type: Journal Article. X-121430017
675 Hopkins IM, Gower MW, Perez TA, . Avatar assistant: improving social skills in students with an ASD through a computer-based intervention. J Autism Dev Disord. 2011 Nov;41(11):1543–55. doi: 10.1007/s10803-011-1179-z. X-1, X-321287255
676 Howlett MA, Sidener TM, Progar PR, . Manipulation of motivating operations and use of a script-fading procedure to teach mands for location to children with language delays. J Appl Behav Anal. 2011 Winter;44(4):943–7. doi: 10.1901/jaba.2011.44-943. X-3, X-422219545
677 Hussein H, Taha GR, Almanasef A. Characteristics of autism spectrum disorders in a sample of egyptian and saudi patients: transcultural cross sectional study. Child Adolesc Psychiatry Ment Health. 2011;5:34. doi: 10.1186/1753-2000-5-34. X-122051160
678 Hvidtjorn D, Grove J, Schendel D, . Risk of autism spectrum disorders in children born after assisted conception: a population-based follow-up study. J Epidemiol Community Health. 2011 Jun;65(6):497–502. doi: 10.1136/jech.2009.093823. X-120584728
679 Ingvarsson ET, Hollobaugh T. A comparison of prompting tactics to establish intraverbals in children with autism. J Appl Behav Anal. 2011 Fall;44(3):659–64. doi: 10.1901/jaba.2011.44-659. X-3, X-421941400
680 Ingvarsson ET, Le DD. Further evaluation of prompting tactics for establishing intraverbal responding in children with autism. Anal Verbal Behav. 2011;27(1):75–93. X-122532756
681 Irwin JR, Tornatore LA, Brancazio L, . Can children with autism spectrum disorders “hear” a speaking face? Child Dev. 2011 Sep–Oct;82(5):1397–403. doi: 10.1111/j.1467-8624.2011.01619.x. X-121790542
682 Ishikawa T, Takahashi K, Ikeda N, . Transporter-Mediated Drug Interaction Strategy for 5-Aminolevulinic Acid (ALA)-Based Photodynamic Diagnosis of Malignant Brain Tumor: Molecular Design of ABCG2 Inhibitors. Pharmaceutics. 2011;3(3):615–35. doi: 10.3390/pharmaceutics3030615. X-1
683 Jaber MA. Dental caries experience, oral health status and treatment needs of dental patients with autism. J Appl Oral Sci. 2011 May–Jun;19(3):212–7. X-121625735
684 Jepson B, Granpeesheh D, Tarbox J, . Controlled evaluation of the effects of hyperbaric oxygen therapy on the behavior of 16 children with autism spectrum disorders. J Autism Dev Disord. 2011 May;41(5):575–88. doi: 10.1007/s10803-010-1075-y. X-3, X-420680427
685 Jeste SS. The neurology of autism spectrum disorders. Current Opinion in Neurology. 2011;24(2):132–9 8p. doi: 10.1097/WCO.0b013e3283446450. Language: English. Entry Date: 20110527. Revision Date: 20150711. Publication Type: Journal Article. X-121293268
686 Johnson CR, Handen BL, Zimmer M, . Effects of gluten free / casein free diet in young children with autism: A pilot study. Journal of Developmental and Physical Disabilities. 2011 2015-12-09;23(3):213–25. doi: http://dx.doi.org/10.1007/s10882-010-9217-x; 2011-08445-004.
687 Joosten A. Evidence-based occupational therapy with children with autism: using information about sensory processing to increase the child’s participation in daily life…Occupational Therapy Australia, 24th National Conference and Exhibition, 29 June – 1 July 2011. Australian Occupational Therapy Journal. 2011;58:93- 1p. doi: 10.1111/j.1440-1630.2011.00938.x. Language: English. Entry Date: 20111209. Revision Date: 20150711. Publication Type: Journal Article. X-5
688 Kaluzna-Czaplinska J, Michalska M, Rynkowski J. Vitamin supplementation reduces the level of homocysteine in the urine of autistic children. Nutr Res. 2011 Apr;31(4):318–21. doi: 10.1016/j.nutres.2011.03.009. X-321530806
689 Kaluzna-Czaplinska J, Socha E, Rynkowski J. B vitamin supplementation reduces excretion of urinary dicarboxylic acids in autistic children. Nutr Res. 2011 Jul;31(7):497–502. doi: 10.1016/j.nutres.2011.06.002. X-1, X-321840465
690 Kamp-Becker I, Schroder J, Muehlan H, . Health-related quality of life in children and adolescents with autism spectrum disorder. Z Kinder Jugendpsychiatr Psychother. 2011 Mar;39(2):123–31. doi: 10.1024/1422-4917/a000098. X-121442600
691 Karsten AM, Carr JE, Lepper TL. Description of a practitioner model for identifying preferred stimuli with individuals with autism spectrum disorders. Behav Modif. 2011 Jul;35(4):347–69. doi: 10.1177/0145445511405184. X-121613240
692 Kern JK, Fletcher CL, Garver CR, . Prospective trial of equine-assisted activities in autism spectrum disorder. Altern Ther Health Med. 2011 May–Jun;17(3):14–20. X-322164808
693 Kern JK, Geier DA, Adams JB, . A clinical trial of glutathione supplementation in autism spectrum disorders. Med Sci Monit. 2011 Dec;17(12):Cr677–82. X-1, X-322129897
694 Khanna R, Madhavan SS, Smith MJ, . Assessment of health-related quality of life among primary caregivers of children with autism spectrum disorders. J Autism Dev Disord. 2011 Sep;41(9):1214–27. doi: 10.1007/s10803-010-1140-6. X-121103917
695 Kim HJ, Lee JE, Shin SJ, . Analysis of the substantia innominata volume in patients with Parkinson’s disease with dementia, dementia with lewy bodies, and Alzheimer’s disease. J Mov Disord. 2011 Oct;4(2):68–72. doi: 10.14802/jmd.11014. X-124868398
696 Kim WS. Mammalian target of rapamycin inhibitors for treatment in tuberous sclerosis. Korean J Pediatr. 2011 Jun;54(6):241–5. doi: 10.3345/kjp.2011.54.6.241. X-121949518
697 King CR. A novel embryological theory of autism causation involving endogenous biochemicals capable of initiating cellular gene transcription: a possible link between twelve autism risk factors and the autism ‘epidemic’. Med Hypotheses. 2011 May;76(5):653–60. doi: 10.1016/j.mehy.2011.01.024. X-121388746
698 Kliebert ML, Tiger JH. Direct and distal effects of noncontingent juice on rumination exhibited by a child with autism. J Appl Behav Anal. 2011 Winter;44(4):955–9. doi: 10.1901/jaba.2011.44-955. X-3, X-422219547
699 Klintwall L, Holm A, Eriksson M, . Sensory abnormalities in autism. A brief report. Res Dev Disabil. 2011 Mar–Apr;32(2):795–800. doi: 10.1016/j.ridd.2010.10.021. X-121111574
700 Knickmeyer RC, Davenport M. Turner syndrome and sexual differentiation of the brain: implications for understanding male-biased neurodevelopmental disorders. J Neurodev Disord. 2011 Dec;3(4):293–306. doi: 10.1007/s11689-011-9089-0. X-121818630
701 Kohls G, Peltzer J, Schulte-Rüther M, . Atypical Brain Responses to Reward Cues in Autism as Revealed by Event-Related Potentials. Journal of Autism & Developmental Disorders. 2011;41(11):1523–33 11p. doi: 10.1007/s10803-011-1177-1. Language: English. Entry Date: 20111109. Revision Date: 20150711. Publication Type: Journal Article. X-121290174
702 Komoto Y, Hashimoto N, Ikegami Y. [Effects of autism features on alcoholism--especially from the aspect of recovery promoting factors]. Nihon Arukoru Yakubutsu Igakkai Zasshi. 2011 Oct;46(5):454–68; discussion 69. X-122256594
703 Kott KM, Nervik D. Book reviews. Pediatric Physical Therapy. 2011 2011 Winter;23(4):408–10 3p. Language: English. Entry Date: 20120210. Revision Date: 20150712. Publication Type: Journal Article. X-1
704 Kovshoff H, Hastings RP, Remington B. Two-year outcomes for children with autism after the cessation of early intensive behavioral intervention. Behav Modif. 2011 Sep;35(5):427–50. doi: 10.1177/0145445511405513. X-121586502
705 Kuehn BM. Scientists probe oxytocin therapy for social deficits in autism, schizophrenia. JAMA: Journal of the American Medical Association. 2011;305(7):659–61 3p. doi: 10.1001/jama.2011.117. Language: English. Entry Date: 20110304. Revision Date: 20150711. Publication Type: Journal Article. Journal Subset: Biomedical. X-1, X-221325177
706 Kunda M, Goel AK. Thinking in Pictures as a Cognitive Account of Autism. Journal of Autism & Developmental Disorders. 2011;41(9):1157–77 21p. doi: 10.1007/s10803-010-1137-1. Language: English. Entry Date: 20110831. Revision Date: 20150711. Publication Type: Journal Article. X-121103918
707 Kurtz AL, Kaufer DI. Dementia in Parkinson’s disease. Curr Treat Options Neurol. 2011 Jun;13(3):242–54. doi: 10.1007/s11940-011-0121-1. X-121461668
708 Kushki A, Chau T, Anagnostou E. Handwriting difficulties in children with autism spectrum disorders: A scoping review. Journal of Autism and Developmental Disorders. 2011 2015-12-09;41(12):1706–16. doi: http://dx.doi.org/10.1007/s10803-011-1206-0; 2011-26942-013. X-1, X-221350917
709 Kwakye LD, Foss-Feig JH, Cascio CJ, . Altered auditory and multisensory temporal processing in autism spectrum disorders. Front Integr Neurosci. 2011;4:129. doi: 10.3389/fnint.2010.00129. X-121258617
710 Lahiri U, Trewyn A, Warren Z, . Dynamic Eye gaze and its Potential in Virtual Reality Based Applications for Children with Autism Spectrum Disorders. Autism Open Access. 2011;1(1) doi: 10.4172/2165-7890.1000101. X-1, X-3, X-4
711 Lahiri U, Warren Z, Sarkar N. Design of a gaze-sensitive virtual social interactive system for children with autism. IEEE Trans Neural Syst Rehabil Eng. 2011 Aug;19(4):443–52. doi: 10.1109/tnsre.2011.2153874. X-121609889
712 Lampi KM, Banerjee PN, Gissler M, . Finnish Prenatal Study of Autism and Autism Spectrum Disorders (FIPS-A): overview and design. J Autism Dev Disord. 2011 Aug;41(8):1090–6. doi: 10.1007/s10803-010-1132-6. X-121082229
713 Landa RJ, Holman KC, O’Neill AH, . Intervention targeting development of socially synchronous engagement in toddlers with autism spectrum disorder: a randomized controlled trial. J Child Psychol Psychiatry. 2011 Jan;52(1):13–21. doi: 10.1111/j.1469-7610.2010.02288.x. X-121126245
714 Lang R, Mahoney R, El Zein F, . Evidence to practice: treatment of anxiety in individuals with autism spectrum disorders. Neuropsychiatr Dis Treat. 2011;7:27–30. doi: 10.2147/ndt.s10327. X-1, X-221326652
715 Lanovaz MJ, Sladeczek IE, Rapp JT. Effects of music on vocal stereotypy in children with autism. J Appl Behav Anal. 2011 Fall;44(3):647–51. doi: 10.1901/jaba.2011.44-647. X-3, X-421941398
716 Larson HJ, Cooper LZ, Eskola J, . Addressing the vaccine confidence gap. Lancet. 2011 Aug 6;378(9790):526–35. doi: 10.1016/s0140-6736(11)60678-8. X-121664679
717 LaRue RH, Sloman KN, Weiss MJ, . Correspondence between traditional models of functional analysis and a functional analysis of manding behavior. Res Dev Disabil. 2011 Nov–Dec;32(6):2449–57. doi: 10.1016/j.ridd.2011.07.015. X-121821393
718 Lehtimaki KA, Liimatainen S, Peltola J, . The serum level of interleukin-6 in patients with intellectual disability and refractory epilepsy. Epilepsy Res. 2011 Jun;95(1–2):184–7. doi: 10.1016/j.eplepsyres.2011.03.004. X-121530175
719 Lemmon ME, Gregas M, Jeste SS. Risperidone use in autism spectrum disorders: a retrospective review of a clinic-referred patient population. J Child Neurol. 2011 Apr;26(4):428–32. doi: 10.1177/0883073810382143. X-320929907
720 Lemon J, Gargaro B, Enticott P, . Brief report: executive functioning in autism spectrum disorders: a gender comparison of response inhibition. Journal of Autism & Developmental Disorders. 2011;41(3):352–6 5p. doi: 10.1007/s10803-010-1039-2. Language: English. Entry Date: 20110419. Revision Date: 20150711. Publication Type: Journal Article. X-120506000
721 Lerman DC, Dittlinger LH, Fentress G, . A comparison of methods for collecting data on performance during discrete trial teaching. Behav Anal Pract. 2011 Summer;4(1):53–62. X-1
722 Lerner MD, Mikami AY, Levine K. Socio-dramatic affective-relational intervention for adolescents with asperger syndrome & high functioning autism: pilot study. Autism. 2011 Jan;15(1):21–42. doi: 10.1177/1362361309353613. X-120923890
723 Leupen A. Helium and autism. Homoeopathic Links. 2011 2011 Summer;24(2):106- 1p. doi: 10.1055/s-0030-1271051. Language: English. Entry Date: 20110729. Revision Date: 20150712. Publication Type: Journal Article. Journal Subset: Alternative/Complementary Therapies. X-1, X-2
724 Li N, Jin BX, Li JL, . [Treatment of autism with scalp acupunctur]. Zhongguo Zhen Jiu. 2011 Aug;31(8):692–6. X-121894689
725 Lim HA, Draper E. The effects of music therapy incorporated with applied behavior analysis verbal behavior approach for children with autism spectrum disorders. J Music Ther. 2011 Winter;48(4):532–50. X-322506303
726 Long C, Gurka MJ, Blackman J. Cognitive Skills of Young Children with and without Autism Spectrum Disorder Using the BSID-III. Autism Res Treat. 2011;2011:759289. doi: 10.1155/2011/759289. X-122937256
727 Lonsdale D, Shamberger RJ, Obrenovich ME. Dysautonomia in autism spectrum disorder: case reports of a family with review of the literature. Autism Res Treat. 2011;2011:129795. doi: 10.1155/2011/129795. X-1, X-3, X-422937241
728 Lopez Moratalla N, Palacios Ortega S. [Delay the age of procreation, decline in fertility and increased use of assisted reproduction: risk of birth defects]. Cuad Bioet. 2011 May–Aug;22(75):259–72. X-122040138
729 Macdonald M, Esposito P, Ulrich D. The physical activity patterns of children with autism. BMC Res Notes. 2011;4:422. doi: 10.1186/1756-0500-4-422. X-122008607
730 Mace FC, Pratt JL, Prager KL, . An evaluation of three methods of saying “no” to avoid an escalating response class hierarchy. J Appl Behav Anal. 2011 Spring;44(1):83–94. doi: 10.1901/jaba.2011.44-83. X-121541139
731 MacFabe DF, Cain NE, Boon F, . Effects of the enteric bacterial metabolic product propionic acid on object-directed behavior, social behavior, cognition, and neuroinflammation in adolescent rats: Relevance to autism spectrum disorder. Behav Brain Res. 2011 Feb 2;217(1):47–54. doi: 10.1016/j.bbr.2010.10.005. X-120937326
732 Magiati I, Moss J, Yates R, . Is the Autism Treatment Evaluation Checklist a useful tool for monitoring progress in children with autism spectrum disorders? J Intellect Disabil Res. 2011 Mar;55(3):302–12. doi: 10.1111/j.1365-2788.2010.01359.x. X-1, X-321199043
733 Magnee MJ, de Gelder B, van Engeland H, . Multisensory integration and attention in autism spectrum disorder: evidence from event-related potentials. PLoS One. 2011;6(8):e24196. doi: 10.1371/journal.pone.0024196. X-121887382
734 Magnée MJCM, de Gelder B, van Engeland H, . Multisensory integration and attention in autism spectrum disorder: Evidence from event-related potentials. PLoS ONE. 2011 2015-12-09;6(8); 2011-20677-001. X-1
735 Makkonen I, Kokki H, Kuikka J, . Effects of fluoxetine treatment on striatal dopamine transporter binding and cerebrospinal fluid insulin-like growth factor-1 in children with autism. Neuropediatrics. 2011 Oct;42(5):207–9. doi: 10.1055/s-0031-1291242. X-1, X-322015434
736 Malisza KL, Clancy C, Shiloff D, . Functional evaluation of hidden figures object analysis in children with autistic disorder. Journal of Autism & Developmental Disorders. 2011;41(1):13–22 10p. doi: 10.1007/s10803-010-1013-z. Language: English. Entry Date: 20110228. Revision Date: 20150711. Publication Type: Journal Article. X-120411412
737 Maljaars JPW, Noens ILJ, Scholte EM, . Visual local and global processing in low-functioning deaf individuals with and without autism spectrum disorder. Journal of Intellectual Disability Research. 2011;55(1):95–105 11p. doi: 10.1111/j.1365-2788.2010.01351.x. Language: English. Entry Date: 20110407. Revision Date: 20150711. Publication Type: Journal Article. X-121108678
738 Marcus RN, Owen R, Manos G, . Aripiprazole in the treatment of irritability in pediatric patients (aged 6–17 years) with autistic disorder: results from a 52-week, open-label study. J Child Adolesc Psychopharmacol. 2011 Jun;21(3):229–36. doi: 10.1089/cap.2009.0121.21663425
739 Marcus RN, Owen R, Manos G, . Safety and tolerability of aripiprazole for irritability in pediatric patients with autistic disorder: a 52-week, open-label, multicenter study. J Clin Psychiatry. 2011 Sep;72(9):1270–6. doi: 10.4088/JCP.09m05933.21813076
740 Margoob MA, Mushtaq D. Serotonin transporter gene polymorphism and psychiatric disorders: is there a link? Indian J Psychiatry. 2011 Oct;53(4):289–99. doi: 10.4103/0019-5545.91901. X-122303036
741 Marquenie K, Rodger S, Mangohig K, . Dinnertime and bedtime routines and rituals in families with a young child with an autism spectrum disorder. Aust Occup Ther J. 2011 Jun;58(3):145–54. doi: 10.1111/j.1440-1630.2010.00896.x. X-121599679
742 Marzullo-Kerth D, Reeve SA, Reeve KF, . Using multiple-exemplar training to teach a generalized repertoire of sharing to children with autism. J Appl Behav Anal. 2011 Summer;44(2):279–94. doi: 10.1901/jaba.2011.44-279. X-1, X-321709784
743 Mashal N, Kasirer A. Thinking maps enhance metaphoric competence in children with autism and learning disabilities. Res Dev Disabil. 2011 Nov–Dec;32(6):2045–54. doi: 10.1016/j.ridd.2011.08.012. X-1, X-321985987
744 Masliyah T, Ad-Dab’bagh Y. Low-Dose Risperidone-Induced Oculogyric Crises in an Adolescent Male with Autism, Tourette’s and Developmental Delay. J Can Acad Child Adolesc Psychiatry. 2011 Aug;20(3):214–6. X-121804851
745 Mason MC. Head for bed. Nurs Stand. 2011 Jan 26–Feb 1;25(21):20. X-1
746 Mathewson KJ, Drmic IE, Jetha MK, . Behavioral and cardiac responses to emotional stroop in adults with autism spectrum disorders: influence of medication. Autism Res. 2011 Apr;4(2):98–108. doi: 10.1002/aur.176. X-121360828
747 Matisz CE, McDougall JJ, Sharkey KA, . Helminth parasites and the modulation of joint inflammation. J Parasitol Res. 2011;2011:942616. doi: 10.1155/2011/942616. X-121584243
748 Matson JL, Wilkins J, Fodstad JC. The Validity of the Baby and Infant Screen for Children with aUtIsm Traits: Part 1 (BISCUIT: Part 1). Journal of Autism & Developmental Disorders. 2011;41(9):1139–46 8p. doi: 10.1007/s10803-010-0973-3. Language: English. Entry Date: 20110831. Revision Date: 20150711. Publication Type: Journal Article. X-120177764
749 Mavropoulou S, Papadopoulou E, Kakana D. Effects of task organization on the independent play of students with autism spectrum disorders. J Autism Dev Disord. 2011 Jul;41(7):913–25. doi: 10.1007/s10803-010-1116-6. X-1, X-3, X-420960042
750 Mazefsky CA, Kao J, Oswald DP. Preliminary evidence suggesting caution in the use of psychiatric self-report measures with adolescents with high-functioning autism spectrum disorders. Res Autism Spectr Disord. 2011 Jan;5(1):164–74. doi: 10.1016/j.rasd.2010.03.006. X-124013401
751 Mazzei D, Lazzeri N, Billeci L, . Development and evaluation of a social robot platform for therapy in autism. Conf Proc IEEE Eng Med Biol Soc. 2011;2011:4515–8. doi: 10.1109/iembs.2011.6091119. X-122255342
752 McLennan Y, Polussa J, Tassone F, . Fragile x syndrome. Curr Genomics. 2011 May;12(3):216–24. doi: 10.2174/138920211795677886. X-122043169
753 Mechling L, Savidge E. Using a Personal Digital Assistant to Increase Completion of Novel Tasks and Independent Transitioning by Students with Autism Spectrum Disorder. Journal of Autism & Developmental Disorders. 2011;41(6):687–704 18p. doi: 10.1007/s10803-010-1088-6. Language: English. Entry Date: 20110719. Revision Date: 20150711. Publication Type: Journal Article. X-3, X-420714798
754 Mehta MV, Gandal MJ, Siegel SJ. mGluR5-antagonist mediated reversal of elevated stereotyped, repetitive behaviors in the VPA model of autism. PLoS One. 2011;6(10):e26077. doi: 10.1371/journal.pone.0026077. X-122016815
755 Miller JS, Gabrielsen T, Villalobos M, . The each child study: systematic screening for autism spectrum disorders in a pediatric setting. Pediatrics. 2011 May;127(5):866–71. doi: 10.1542/peds.2010-0136. X-121482605
756 Mills R, Marchant S. Feature: Intervention in autism: a brief review of the literature. Tizard Learning Disability Review. 2011;16(4):20–35 16p. doi: 10.1108/13595471111172822. Language: English. Entry Date: 20111016. Revision Date: 20150711. Publication Type: Journal Article. X-1, X-2
757 Milne E. Increased intra-participant variability in children with autistic spectrum disorders: evidence from single-trial analysis of evoked EEG. Front Psychol. 2011;2:51. doi: 10.3389/fpsyg.2011.00051. X-121716921
758 Minchella L, Preti L. Autism spectrum disorder: clinical considerations for the school nurse. NASN Sch Nurse. 2011 May;26(3):143–5. X-121675293
759 Mines MA, Jope RS. Glycogen synthase kinase-3: a promising therapeutic target for fragile x syndrome. Front Mol Neurosci. 2011;4:35. doi: 10.3389/fnmol.2011.00035. X-122053151
760 Ming X, Hashim A, Fleishman S, . Access to specialty care in autism spectrum disorders-a pilot study of referral source. BMC Health Serv Res. 2011;11:99. doi: 10.1186/1472-6963-11-99. X-121569571
761 Minjarez MB, Williams SE, Mercier EM, . Pivotal response group treatment program for parents of children with autism. J Autism Dev Disord. 2011 Jan;41(1):92–101. doi: 10.1007/s10803-010-1027-6. X-1, X-320440638
762 Montes G, Halterman JS. White-black disparities in family-centered care among children with autism in the United States: evidence from the NS-CSHCN 2005–2006. Acad Pediatr. 2011 Jul–Aug;11(4):297–304. doi: 10.1016/j.acap.2011.02.002. X-121622042
763 Montgomery J, Storey K, Post M, . The use of auditory prompting systems for increasing independent performance of students with autism in employment training. Int J Rehabil Res. 2011 Dec;34(4):330–5. doi: 10.1097/MRR.0b013e32834a8fa8. X-3, X-421885987
764 Moore TR, Symons FJ. Adherence to treatment in a behavioral intervention curriculum for parents of children with autism spectrum disorder. Behav Modif. 2011 Nov;35(6):570–94. doi: 10.1177/0145445511418103. X-1, X-321885470
765 Morrison H, Roscoe EM, Atwell A. An evaluation of antecedent exercise on behavior maintained by automatic reinforcement using a three-component multiple schedule. J Appl Behav Anal. 2011 Fall;44(3):523–41. doi: 10.1901/jaba.2011.44-523. X-121941383
766 Mrozek-Budzyn D, Majewska R, Kieltyka A, . [Lack of association between thimerosal-containing vaccines and autism]. Przegl Epidemiol. 2011;65(3):491–5. X-122184954
767 Myck-Wayne J, Robinson S, Henson E. Serving and supporting young children with a dual diagnosis of hearing loss and autism: the stories of four families. Am Ann Deaf. 2011 Fall;156(4):379–90. X-122256539
768 Nadeau J, Sulkowski ML, Ung D, . Treatment of comorbid anxiety and autism spectrum disorders. Neuropsychiatry (London). 2011 Dec;1(6):567–78. X-1, X-224174992
769 Nadel J, Aouka N, Coulon N, . Yes they can! Autism: The International Journal of Research & Practice. 2011;15(4):421–35 15p. doi: 10.1177/1362361310386508. Language: English. Entry Date: 20110901. Revision Date: 20150711. Publication Type: Journal Article. X-121454387
770 Nagel JD, Rudick J. Abstracts from the NIH Office of Research on Women’s Health Eighth Annual Interdisciplinary Women’s Health Research Symposium November 17, 2011. Journal of Women’s Health (15409996). 2011;20(10):1382–413 32p. doi: 10.1089/jwh.2011.Ab02. Language: English. Entry Date: 20111025. Revision Date: 20150711. Publication Type: Journal Article. X-1
771 Narendorf SC, Shattuck PT, Sterzing PR. Mental health service use among adolescents with an autism spectrum disorder. Psychiatr Serv. 2011 Aug;62(8):975–8. doi: 10.1176/appi.ps.62.8.975. X-121807842
772 Nazeer A. Psychopharmacology of autistic spectrum disorders in children and adolescents. Pediatric Clinics of North America. 2011;58(1):85–97 13p. doi: 10.1016/j.pcl.2010.10.011. Language: English. Entry Date: 20110401. Revision Date: 20150711. Publication Type: Journal Article. X-1, X-221281850
773 Niederhofer H. Efficacy of duloxetine and agomelatine does not exceed that of other antidepressants in patients with autistic disorder: preliminary results in 3 patients. Prim Care Companion CNS Disord. 2011;13(1) doi: 10.4088/PCC.10l01038blu. X-1, X-2
774 Normand MP, Beaulieu L. Further evaluation of response-independent delivery of preferred stimuli and child compliance. J Appl Behav Anal. 2011 Fall;44(3):665–9. doi: 10.1901/jaba.2011.44-665. X-1, X-3, X-421941401
775 O’Brien K, Slaughter V, Peterson CC. Sibling influences on theory of mind development for children with ASD. J Child Psychol Psychiatry. 2011 Jun;52(6):713–9. doi: 10.1111/j.1469-7610.2011.02389.x. X-121418062
776 Obrusnikova I, Dillon SR. Challenging situations when teaching children with autism spectrum disorders in general physical education. Adapt Phys Activ Q. 2011 Apr;28(2):113–31. X-121757784
777 O’Keeffe N, McNicholas F. Paediatricians’ views on their role in the assessment and management of ADHD and autism. Ir Med J. 2011 Oct;104(9):282–4. X-122132601
778 Oldershaw A, Treasure J, Hambrook D, . Is anorexia nervosa a version of autism spectrum disorders? European Eating Disorders Review. 2011;19(6):462–74 13p. doi: 10.1002/erv.1069. Language: English. Entry Date: 20120112. Revision Date: 20150711. Publication Type: Journal Article. X-121280165
779 Olivar-Parra JS, De-La-Iglesia-Gutierrez M, Forns M. Training referential communicative skills to individuals with autism spectrum disorder: a pilot study. Psychol Rep. 2011 Dec;109(3):921–39. doi: 10.2466/10.11.15.28.pr0.109.6.921-939. X-122420121
780 Oriel KN, George CL, Peckus R, . The effects of aerobic exercise on academic engagement in young children with autism spectrum disorder. Pediatr Phys Ther. 2011 Summer;23(2):187–93. doi: 10.1097/PEP.0b013e318218f149. X-121552085
781 Orsmond GI, Kuo HY. The daily lives of adolescents with an autism spectrum disorder: discretionary time use and activity partners. Autism. 2011 Sep;15(5):579–99. doi: 10.1177/1362361310386503. X-121697194
782 Pajareya K, Nopmaneejumruslers K. A pilot randomized controlled trial of DIR/Floortime parent training intervention for pre-school children with autistic spectrum disorders. Autism. 2011 Sep;15(5):563–77. doi: 10.1177/1362361310386502. X-121690083
783 Palmen A, Didden R, Korzilius H. An outpatient group training programme for improving leisure lifestyle in high-functioning young adults with ASD: a pilot study. Dev Neurorehabil. 2011;14(5):297–309. doi: 10.3109/17518423.2011.595433. X-121870954
784 Pang KH, Croaker GD. Constipation in children with autism and autistic spectrum disorder. Pediatr Surg Int. 2011 Apr;27(4):353–8. doi: 10.1007/s00383-010-2680-8. X-120697898
785 Papavasiliou AS, Nikaina I, Rizou J, . The effect of a psycho-educational program on CARS scores and short sensory profile in autistic children. Eur J Paediatr Neurol. 2011 Jul;15(4):338–44. doi: 10.1016/j.ejpn.2011.02.004. X-321354837
786 Park JY, Zhang HY, Oh MC. New technical tip for anterior cervical plating : make hole first and choose the proper plate size later. J Korean Neurosurg Soc. 2011 Apr;49(4):212–6. doi: 10.3340/jkns.2011.49.4.212. X-121607178
787 Park KW, Kim HS, Cheon SM, . Dementia with Lewy Bodies versus Alzheimer’s Disease and Parkinson’s Disease Dementia: A Comparison of Cognitive Profiles. J Clin Neurol. 2011 Mar;7(1):19–24. doi: 10.3988/jcn.2011.7.1.19. X-121519522
788 Pasco G, Tohill C. Predicting progress in Picture Exchange Communication System (PECS) use by children with autism. Int J Lang Commun Disord. 2011 Jan–Feb;46(1):120–5. doi: 10.3109/13682822.2010.484851. X-120536353
789 Patil RR. MMR vaccination and autism: learnings and implications. Hum Vaccin. 2011 Feb;7(2):281–2. X-121343697
790 Patten E, Watson LR. Interventions targeting attention in young children with autism. Am J Speech Lang Pathol. 2011 Feb;20(1):60–9. doi: 10.1044/1058-0360(2010/09-0081). X-1, X-2, X-320739632
791 Petursdottir AI, Carp CL, Matthies DW, . Analyzing stimulus-stimulus pairing effects on preferences for speech sounds. Anal Verbal Behav. 2011;27(1):45–60. X-122532754
792 Pierpont EI, Richmond EK, Abbeduto L, . Contributions of phonological and verbal working memory to language development in adolescents with fragile X syndrome. J Neurodev Disord. 2011 Dec;3(4):335–47. doi: 10.1007/s11689-011-9095-2. X-121993552
793 Pillay M, Alderson-Day B, Wright B, . Autism Spectrum Conditions--enhancing Nurture and Development (ASCEND): an evaluation of intervention support groups for parents. Clin Child Psychol Psychiatry. 2011 Jan;16(1):5–20. doi: 10.1177/1359104509340945. X-320223793
794 Plavnick JB, Ferreri SJ. Establishing verbal repertoires in children with autism using function-based video modeling. J Appl Behav Anal. 2011 Winter;44(4):747–66. doi: 10.1901/jaba.2011.44-747. X-1, X-422219527
795 Polsek D, Jagatic T, Cepanec M, . RECENT DEVELOPMENTS IN NEUROPATHOLOGY OF AUTISM SPECTRUM DISORDERS. Transl Neurosci. 2011;2(3):256–64. X-122180840
796 Poon KK. The activities and participation of adolescents with autism spectrum disorders in Singapore: findings from an ICF-based instrument. J Intellect Disabil Res. 2011 Aug;55(8):790–800. doi: 10.1111/j.1365-2788.2011.01397.x. X-121375640
797 Powell SG, Thomsen PH, Frydenberg M, . Long-term treatment of ADHD with stimulants: a large observational study of real-life patients. J Atten Disord. 2011 Aug;15(6):439–51. doi: 10.1177/1087054710368486. X-120631198
798 Puleo CM, Kendall PC. Anxiety disorders in typically developing youth: autism spectrum symptoms as a predictor of cognitive-behavioral treatment. J Autism Dev Disord. 2011 Mar;41(3):275–86. doi: 10.1007/s10803-010-1047-2. X-120694508
799 Qian N, Lipkin RM. A learning-style theory for understanding autistic behaviors. Front Hum Neurosci. 2011;5:77. doi: 10.3389/fnhum.2011.00077. X-121886617
800 Quigley SP, Peterson L, Frieder JE, . Effects of a weighted vest on problem behaviors during functional analyses in children with Pervasive Developmental Disorders. Research in Autism Spectrum Disorders. 2011 2015-12-09;5(1):529–38. doi: 10.1901/jaba.1994.27-197. (Reprinted from Analysis and Intervention in Developmental Disabilities, 1982, Vol. 2, pp. 3–20) http://dx.doi.org/10.1016/j.rasd.2010.06.019; 2010-22960-057. X-3, X-4
801 Ramachandran VS, Seckel EL. Synchronized dance therapy to stimulate mirror neurons in autism. Med Hypotheses. 2011 Jan;76(1):150–1. doi: 10.1016/j.mehy.2010.10.047. X-2
802 Ray-Subramanian CE, Huai N, Ellis Weismer S. Brief report: adaptive behavior and cognitive skills for toddlers on the autism spectrum. J Autism Dev Disord. 2011 May;41(5):679–84. doi: 10.1007/s10803-010-1083-y. X-120697794
803 Reed P, Staytom L, Stott S, . Comparison of conditioning impairments in children with Down syndrome, autistic spectrum disorders and mental age-matched controls. J Intellect Disabil Res. 2011 Oct;55(10):988–97. doi: 10.1111/j.1365-2788.2011.01454.x. X-121790825
804 Reynolds KE. Autism spectrum disorders in childhood: a clinical update. Community Pract. 2011 Jul;84(7):36–8. X-1, X-2, X-3
805 Rezendes DL, Scarpa A. Associations between Parental Anxiety/Depression and Child Behavior Problems Related to Autism Spectrum Disorders: The Roles of Parenting Stress and Parenting Self-Efficacy. Autism Res Treat. 2011;2011:395190. doi: 10.1155/2011/395190. X-122937246
806 Richling SM, Rapp JT, Carroll RA, . Using noncontingent reinforcement to increase compliance with wearing prescription prostheses. J Appl Behav Anal. 2011 Summer;44(2):375–9. doi: 10.1901/jaba.2011.44-375. X-1, X-3, X-421709796
807 Ridge K, Guerin S. Irish clinicians’ views of interventions for children with autistic spectrum disorders. Autism. 2011 Mar;15(2):239–52. doi: 10.1177/1362361310364141. X-121325370
808 Riviere V, Becquet M, Peltret E, . Increasing compliance with medical examination requests directed to children with autism: effects of a high-probability request procedure. J Appl Behav Anal. 2011 Spring;44(1):193–7. doi: 10.1901/jaba.2011.44-193. X-1, X-321541109
809 Robb AS, Andersson C, Bellocchio EE, . Safety and tolerability of aripiprazole in the treatment of irritability associated with autistic disorder in pediatric subjects (6–17 years old):results from a pooled analysis of 2 studies. Prim Care Companion CNS Disord. 2011;13(1) doi: 10.4088/PCC.10m01008gry.
810 Roberts JE, Miranda M, Boccia M, . Treatment effects of stimulant medication in young boys with fragile X syndrome. J Neurodev Disord. 2011 Sep;3(3):175–84. doi: 10.1007/s11689-011-9085-4. X-121671049
811 Roberts TP, Cannon KM, Tavabi K, . Auditory magnetic mismatch field latency: a biomarker for language impairment in autism. Biol Psychiatry. 2011 Aug 1;70(3):263–9. doi: 10.1016/j.biopsych.2011.01.015. X-121392733
812 Robinson BH. Understanding ADHD in youth. Acupuncture Today. 2011;12(2):12–24 3p. Language: English. Entry Date: 20110225. Revision Date: 20150711. Publication Type: Journal Article. Journal Subset: Alternative/Complementary Therapies. X-1
813 Rosenberg RE, Kaufmann WE, Law JK, . Parent report of community psychiatric comorbid diagnoses in autism spectrum disorders. Autism Res Treat. 2011;2011:405849. doi: 10.1155/2011/405849. X-122937248
814 Rosenberg RE, Landa R, Law JK, . Factors affecting age at initial autism spectrum disorder diagnosis in a national survey. Autism Res Treat. 2011;2011:874619. doi: 10.1155/2011/874619. X-1, X-322937257
815 Rosenblatt LE, Gorantla S, Torres JA, . Relaxation response-based yoga improves functioning in young children with autism: a pilot study. J Altern Complement Med. 2011 Nov;17(11):1029–35. doi: 10.1089/acm.2010.0834. X-321992466
816 Rothman SM. Health advocacy organizations and evidence-based medicine. Jama. 2011 Jun 22;305(24):2569–70. doi: 10.1001/jama.2011.866. X-121693747
817 Ruble L, Birdwhistell J, Toland MD, . Analysis of Parent, Teacher, and Consultant Speech Exchanges and Educational Outcomes of Students With Autism During COMPASS Consultation. J Educ Psychol Consult. 2011;21(4):259–83. doi: 10.1080/10474412.2011.620818. X-1, X-322639523
818 Ruble LA, Usher EL, McGrew JH. Preliminary Investigation of the Sources of Self-Efficacy Among Teachers of Students with Autism. Focus Autism Other Dev Disabl. 2011 Jun;26(2):67–74. doi: 10.1177/1088357610397345. X-121691453
819 Russo AJ. Increased Copper in Individuals with Autism Normalizes Post Zinc Therapy More Efficiently in Individuals with Concurrent GI Disease. Nutr Metab Insights. 2011;4:49–54. doi: 10.4137/nmi.s6827. X-123946661
820 Russo AJ, Devito R. Analysis of Copper and Zinc Plasma Concentration and the Efficacy of Zinc Therapy in Individuals with Asperger’s Syndrome, Pervasive Developmental Disorder Not Otherwise Specified (PDD-NOS) and Autism. Biomark Insights. 2011;6:127–33. doi: 10.4137/bmi.s7286. X-122174567
821 Saalasti S, Tiippana K, Katsyri J, . The effect of visual spatial attention on audiovisual speech perception in adults with Asperger syndrome. Exp Brain Res. 2011 Sep;213(2–3):283–90. doi: 10.1007/s00221-011-2751-7. X-121660467
822 Saalasti S, Tiippana K, Kätsyri J, . The effect of visual spatial attention on audiovisual speech perception in adults with Asperger syndrome. Experimental Brain Research. 2011 2015-12-09;213(2–3):283–90. doi: http://dx.doi.org/10.1007/s00221-011-2751-7; 2011-18088-015. X-121660467
823 Saint-Andre S, Neira Zalentein W, Robin D, . [Telepsychiatry at the service of autism]. Encephale. 2011 Feb;37(1):18–24. doi: 10.1016/j.encep.2010.03.010. X-1, X-221349370
824 Samson F, Hyde KL, Bertone A, . Atypical processing of auditory temporal complexity in autistics. Neuropsychologia. 2011 Feb;49(3):546–55. doi: 10.1016/j.neuropsychologia.2010.12.033. X-121192958
825 Samyn V, Roeyers H, Bijttebier P. Effortful control in typically developing boys and in boys with ADHD or autism spectrum disorder. Res Dev Disabil. 2011 Mar–Apr;32(2):483–90. doi: 10.1016/j.ridd.2010.12.038. X-121255973
826 Sanchez-Barcelo EJ, Mediavilla MD, Reiter RJ. Clinical uses of melatonin in pediatrics. Int J Pediatr. 2011;2011:892624. doi: 10.1155/2011/892624. X-121760817
827 Sansa G, Carlson C, Doyle W, . Medically refractory epilepsy in autism. Epilepsia. 2011 Jun;52(6):1071–5. doi: 10.1111/j.1528-1167.2011.03069.x. X-1, X-321671922
828 Santesso DL, Drmic IE, Jetha MK, . An event-related source localization study of response monitoring and social impairments in autism spectrum disorder. Psychophysiology. 2011 Feb;48(2):241–51. doi: 10.1111/j.1469-8986.2010.01056.x. X-120557481
829 Sasson NJ, Pinkham AE, Carpenter KL, . The benefit of directly comparing autism and schizophrenia for revealing mechanisms of social cognitive impairment. J Neurodev Disord. 2011 Jun;3(2):87–100. doi: 10.1007/s11689-010-9068-x. X-121484194
830 Scarpa A, Reyes NM. Improving emotion regulation with CBT in young children with high functioning autism spectrum disorders: a pilot study. Behav Cogn Psychother. 2011 Jul;39(4):495–500. doi: 10.1017/s1352465811000063. X-421457605
831 Schaaf R, Blanche E. Comparison of Behavioral Intervention and Sensory-Integration Therapy in the Treatment of Challenging Behavior…Devlin, S., Healy, O., Leader, G., & Hughes, B. M. (2010). Journal of Autism and Developmental Disorders. Advance online publication. doi:10.1007/s10803-010-1149-x. Journal of Autism & Developmental Disorders. 2011;41(10):1436–8 3p. doi: 10.1007/s10803-011-1303-0. Language: English. Entry Date: 20110930. Revision Date: 20150711. Publication Type: Journal Article. X-1, X-221667199
832 Schaaf RC. Interventions that address sensory dysfunction for individuals with autism spectrum disorders: Preliminary evidence for the superiority of sensory integration compared to other sensory approaches. Evidence-based practices and treatments for children with autism.: Springer Science + Business Media, New York, NY; 2011:245–73.
833 Schaaf RC, Toth-Cohen S, Johnson SL, . The everyday routines of families of children with autism: examining the impact of sensory processing difficulties on the family. Autism. 2011 May;15(3):373–89. doi: 10.1177/1362361310386505. X-121430016
834 Schieve LA, Rice C, Devine O, . Have secular changes in perinatal risk factors contributed to the recent autism prevalence increase? Development and application of a mathematical assessment model. Ann Epidemiol. 2011 Dec;21(12):930–45. doi: 10.1016/j.annepidem.2011.08.009. X-122000328
835 Schiff A, Tarbox J, Lanagan T, . Establishing compliance with liquid medication administration in a child with autism. J Appl Behav Anal. 2011 Summer;44(2):381–5. doi: 10.1901/jaba.2011.44-381. X-121709797
836 Schlosser RW, Shane H, Sorce J, . Identifying performing and under performing graphic symbols for verbs and prepositions in animated and static formats: a research note. Augment Altern Commun. 2011 Sep;27(3):205–14. doi: 10.3109/07434618.2011.592217. X-122008033
837 Schmid AM, Truog AW, Damian FJ. Care of the suicidal pediatric patient in the ED: a case study. Am J Nurs. 2011 Sep;111(9):34–43; quiz 4–5. doi: 10.1097/01.NAJ.0000405060.13022.b7. X-1
838 Schmidt C, Stichter JP, Lierheimer K, . An initial investigation of the generalization of a school-based social competence intervention for youth with high-functioning autism. Autism Res Treat. 2011;2011:589539. doi: 10.1155/2011/589539. X-3, X-422937252
839 Schneider HD, Hopp JP. The use of the Bilingual Aphasia Test for assessment and transcranial direct current stimulation to modulate language acquisition in minimally verbal children with autism. Clin Linguist Phon. 2011 Jun;25(6–7):640–54. doi: 10.3109/02699206.2011.570852. X-1, X-3, X-421631313
840 Schoen E, Paul R, Chawarska K. Phonology and vocal behavior in toddlers with autism spectrum disorders. Autism Res. 2011 Jun;4(3):177–88. doi: 10.1002/aur.183. X-121308998
841 Schumacher BI, Rapp JT. Evaluation of the immediate and subsequent effects of response interruption and redirection on vocal stereotypy. J Appl Behav Anal. 2011 Fall;44(3):681–5. doi: 10.1901/jaba.2011.44-681. X-3, X-421941405
842 Scoles HA, Urraca N, Chadwick SW, . Increased copy number for methylated maternal 15q duplications leads to changes in gene and protein expression in human cortical samples. Mol Autism. 2011;2(1):19. doi: 10.1186/2040-2392-2-19. X-122152151
843 Seiverling L, Hendy HM, Williams K. The Screening Tool of Feeding Problems applied to children (STEP-CHILD): psychometric characteristics and associations with child and parent variables. Res Dev Disabil. 2011 May–Jun;32(3):1122–9. doi: 10.1016/j.ridd.2011.01.012. X-121316919
844 Semansky RM, Xie M, Mandell DS. Medicaid’s increasing role in treating youths with autism spectrum disorders. Psychiatr Serv. 2011 Jun;62(6):588. doi: 10.1176/appi.ps.62.6.588. X-121632723
845 Senechal C, Fontaine C, Larivee S, . [Integration in the workforce of Quebec of adults living with Autism Spectrum Disorder or Asperger Syndrome]. Sante Ment Que. 2011 Spring;36(1):181–99. X-1
846 Shattuck PT, Wagner M, Narendorf S, . Post-high school service use among young adults with an autism spectrum disorder. Arch Pediatr Adolesc Med. 2011 Feb;165(2):141–6. doi: 10.1001/archpediatrics.2010.279. X-121300654
847 Shriberg L, Paul R, Black L, . The Hypothesis of Apraxia of Speech in Children with Autism Spectrum Disorder. Journal of Autism & Developmental Disorders. 2011;41(4):405–26 22p. doi: 10.1007/s10803-010-1117-5. Language: English. Entry Date: 20110427. Revision Date: 20150711. Publication Type: Journal Article. X-120972615
848 Sihvonen J. [Neuropsychiatric coaching of an adult with Asperger syndrome]. Duodecim. 2011;127(2):118–25. X-121442862
849 Silva LM, Schalock M, Ayres R. A model and treatment for autism at the convergence of Chinese medicine and Western science: first 130 cases. Chin J Integr Med. 2011 Jun;17(6):421–9. doi: 10.1007/s11655-011-0635-0. X-1, X-2, X-321660676
850 Sofronoff K, Dark E, Stone V. Social vulnerability and bullying in children with Asperger syndrome. Autism. 2011 May;15(3):355–72. doi: 10.1177/1362361310365070. X-121430018
851 Sofronoff K, Eloff J, Sheffield J, . Increasing the understanding and demonstration of appropriate affection in children with asperger syndrome: a pilot trial. Autism Res Treat. 2011;2011:214317. doi: 10.1155/2011/214317. X-322937243
852 Song G, Tin C, Giacometti E, . Habituation without NMDA Receptor-Dependent Desensitization of Hering-Breuer Apnea Reflex in a Mecp2 Mutant Mouse Model of Rett Syndrome. Front Integr Neurosci. 2011;5:6. doi: 10.3389/fnint.2011.00006. X-121629824
853 Spencer L, Lyketsos CG, Samstad E, . A suicidal adult in crisis: an unexpected diagnosis of autism spectrum disorder. Am J Psychiatry. 2011 Sep;168(9):890–2. doi: 10.1176/appi.ajp.2011.10091261. X-121890803
854 Srivastava RK, Agarwal M, Pundhir A. Role of donepezil in autism: its conduciveness in psychopharmacotherapy. Case Rep Psychiatry. 2011;2011:563204. doi: 10.1155/2011/563204. X-3, X-422937405
855 Stahmer AC, Akshoomoff N, Cunningham AB. Inclusion for toddlers with autism spectrum disorders: the first ten years of a community program. Autism. 2011 Sep;15(5):625–41. doi: 10.1177/1362361310392253. X-1, X-321486899
856 Stahmer AC, Brookman-Frazee L, Lee E, . Parent and Multidisciplinary Provider Perspectives on Earliest Intervention for Children at Risk for Autism Spectrum Disorders. Infants Young Child. 2011 Oct;24(4):344–63. X-124058266
857 Stein LI, Polido JC, Mailloux Z, . Oral care and sensory sensitivities in children with autism spectrum disorders. Spec Care Dentist. 2011 May–Jun;31(3):102–10. doi: 10.1111/j.1754-4505.2011.00187.x. X-121592164
858 Stephenson DT, O’Neill SM, Narayan S, . Histopathologic characterization of the BTBR mouse model of autistic-like behavior reveals selective changes in neurodevelopmental proteins and adult hippocampal neurogenesis. Mol Autism. 2011;2(1):7. doi: 10.1186/2040-2392-2-7. X-121575186
859 Stevenson RA, VanDerKlok RM, Pisoni DB, . Discrete neural substrates underlie complementary audiovisual speech integration processes. NeuroImage. 2011 2015-02-24;55(3):1339–45. doi: http://dx.doi.org/10.1016/j.neuroimage.2010.12.063; 2011-02101-001. X-121195198
860 Stocco CS, Thompson RH, Rodriguez NM. Restricted interests and teacher presentation of items. J Appl Behav Anal. 2011 Fall;44(3):499–512. doi: 10.1901/jaba.2011.44-499. X-121941381
861 Stone WS, Iguchi L. Do Apparent Overlaps between Schizophrenia and Autistic Spectrum Disorders Reflect Superficial Similarities or Etiological Commonalities? N Am J Med Sci (Boston). 2011 Jul 25;4(3):124–33. X-122563520
862 Strehle EM. Dysmorphological and pharmacological studies in 4q- syndrome. Genet Couns. 2011;22(2):173–85. X-121848010
863 Suda S, Iwata K, Shimmura C, . Decreased expression of axon-guidance receptors in the anterior cingulate cortex in autism. Mol Autism. 2011;2(1):14. doi: 10.1186/2040-2392-2-14. X-121859478
864 Sumiyoshi C, Kawakubo Y, Suga M, . Impaired ability to organize information in individuals with autism spectrum disorders and their siblings. Neurosci Res. 2011 Mar;69(3):252–7. doi: 10.1016/j.neures.2010.11.007. X-121129422
865 Sundberg ML, Sundberg CA. Intraverbal behavior and verbal conditional discriminations in typically developing children and children with autism. Anal Verbal Behav. 2011;27(1):23–43. X-122532753
866 Sung M, Ooi YP, Goh TJ, . Effects of cognitive-behavioral therapy on anxiety in children with autism spectrum disorders: a randomized controlled trial. Child Psychiatry Hum Dev. 2011 Dec;42(6):634–49. doi: 10.1007/s10578-011-0238-1. X-121660428
867 Tallberg T, Dabek J, Hallamaa R, . Lipidomics: the function of vital lipids in embryogenesis preventing autism spectrum disorders, treating sterile inflammatory diatheses with a lymphopoietic central nervous system component. J Lipids. 2011;2011:137175. doi: 10.1155/2011/137175. X-121490796
868 Tamanaha AC, Perissinoto J. Comparison of the evolutional process of children with autism spectrum disorders in different language therapeutic interventions. J Soc Bras Fonoaudiol. 2011 Mar;23(1):8–12. X-421552726
869 Taylor JL, Seltzer MM. Employment and post-secondary educational activities for young adults with autism spectrum disorders during the transition to adulthood. J Autism Dev Disord. 2011 May;41(5):566–74. doi: 10.1007/s10803-010-1070-3. X-120640591
870 Thomas M, Hunt A, Hurley M, . Time-use diaries are acceptable to parents with a disabled preschool child and are helpful in understanding families’ daily lives. Child Care Health Dev. 2011 Mar;37(2):168–74. doi: 10.1111/j.1365-2214.2010.01156.x. X-120854450
871 Tiinanen S, Maatta A, Silfverhuth M, . HRV and EEG based indicators of stress in children with Asperger syndrome in audio-visual stimulus test. Conf Proc IEEE Eng Med Biol Soc. 2011;2011:2021–4. doi: 10.1109/iembs.2011.6090371. X-122254732
872 Tobiasova Z, van der Lingen KH, Scahill L, . Risperidone-related improvement of irritability in children with autism is not associated with changes in serum of epidermal growth factor and interleukin-13. J Child Adolesc Psychopharmacol. 2011 Dec;21(6):555–64. doi: 10.1089/cap.2010.0134. X-322070180
873 Tops M, van Ijzendoorn MH, Riem MM, . Oxytocin receptor gene associated with the efficiency of social auditory processing. Front Psychiatry. 2011;2:60. doi: 10.3389/fpsyt.2011.00060. X-122069391
874 Trepagnier CY, Olsen DE, Boteler L, . Virtual conversation partner for adults with autism. Cyberpsychol Behav Soc Netw. 2011 Jan–Feb;14(1–2):21–7. doi: 10.1089/cyber.2009.0255. X-121329439
875 Trottier N, Kamp L, Mirenda P. Effects of peer-mediated instruction to teach use of speech-generating devices to students with autism in social game routines. Augment Altern Commun. 2011 Mar;27(1):26–39. doi: 10.3109/07434618.2010.546810. X-3, X-421284561
876 Turner-Brown LM, Lam KS, Holtzclaw TN, . Phenomenology and measurement of circumscribed interests in autism spectrum disorders. Autism. 2011 Jul;15(4):437–56. doi: 10.1177/1362361310386507. X-121454386
877 Umeda C, Deitz J. Effects of therapy cushions on classroom behaviors of children with autism spectrum disorder. Am J Occup Ther. 2011 Mar–Apr;65(2):152–9. X-3, X-421476362
878 Vaidya CJ, Foss-Feig J, Shook D, . Controlling attention to gaze and arrows in childhood: an fMRI study of typical development and Autism Spectrum Disorders. Dev Sci. 2011 Jul;14(4):911–24. doi: 10.1111/j.1467-7687.2011.01041.x. X-121676110
879 Van Adel JM, Geier JD, Perry A, . Credible knowledge: a pilot evaluation of a modified GRADE method using parent-implemented interventions for children with autism. BMC Health Serv Res. 2011;11:60. doi: 10.1186/1472-6963-11-60. X-1, X-2, X-321426564
880 Velasques B, Machado S, Paes F, . Sensorimotor integration and psychopathology: Motor control abnormalities related to psychiatric disorders. The World Journal of Biological Psychiatry. 2011 2015-12-09;12(7–8):560–73. doi: 10.1093/schbul/sbq027. http://dx.doi.org/10.3109/15622975.2010.551405; 2012-00584-010. X-121428729
881 Vyas AK, White NH. Case of hypercalcemia secondary to hypervitaminosis a in a 6-year-old boy with autism. Case Rep Endocrinol. 2011;2011:424712. doi: 10.1155/2011/424712. X-122937283
882 Wachtel LE, Reti IM, Dhossche DM, . Stability of neuropsychological testing during two years of maintenance electroconvulsive therapy in an autistic man. Prog Neuropsychopharmacol Biol Psychiatry. 2011 Jan 15;35(1):301–2. doi: 10.1016/j.pnpbp.2010.11.013. X-1, X-3, X-421111019
883 Walsh MB. The top 10 reasons children with autism deserve ABA. Behav Anal Pract. 2011 Summer;4(1):72–9. X-122532906
884 Wan CY, Bazen L, Baars R, . Auditory-motor mapping training as an intervention to facilitate speech output in non-verbal children with autism: a proof of concept study. PLoS One. 2011;6(9):e25505. doi: 10.1371/journal.pone.0025505. X-3, X-421980480
885 Wei BY, Huang F, Qin XT, . [Treatment of behavioral disorders by risperidone in children with autism]. Zhongguo Dang Dai Er Ke Za Zhi. 2011 Mar;13(3):216–8. X-321426640
886 Welch MG. [Commentary on] Review: secretin is not effective for the treatment of children with autism spectrum disorders. Evidence Based Mental Health. 2011;14(4):104- 1p. doi: 10.1136/ebmh.2011.100131. Language: English. Entry Date: 20111116. Revision Date: 20150711. Publication Type: Journal Article. X-1, X-221954153
887 Westendorp M, Houwen S, Hartman E, . Are gross motor skills and sports participation related in children with intellectual disabilities? Res Dev Disabil. 2011 May–Jun;32(3):1147–53. doi: 10.1016/j.ridd.2011.01.009. X-121310587
888 Westmark CJ, Hervey CM, Berry-Kravis EM, . Effect of Anticoagulants on Amyloid beta-Protein Precursor and Amyloid Beta Levels in Plasma. J Alzheimers Dis Parkinsonism. 2011 Jul 24;1:101. doi: 10.4172/2161-0460.1000101. X-123459194
889 White ER, Hoffmann B, Hoch H, . Teaching teamwork to adolescents with autism: the cooperative use of activity schedules. Behav Anal Pract. 2011 Summer;4(1):27–35. X-122532901
890 Whitehouse AJ, Maybery M, Wray JA, . No association between early gastrointestinal problems and autistic-like traits in the general population. Dev Med Child Neurol. 2011 May;53(5):457–62. doi: 10.1111/j.1469-8749.2011.03915.x. X-121418197
891 Woodard CR, Van Reet J. Object identification and imagination: an alternative to the meta-representational explanation of autism. J Autism Dev Disord. 2011 Feb;41(2):213–26. doi: 10.1007/s10803-010-1044-5. X-120532603
892 Wright B, Sims D, Smart S, . Melatonin versus placebo in children with autism spectrum conditions and severe sleep problems not amenable to behaviour management strategies: a randomised controlled crossover trial. J Autism Dev Disord. 2011 Feb;41(2):175–84. doi: 10.1007/s10803-010-1036-5.20535539
893 Yang M, Perry K, Weber MD, . Social peers rescue autism-relevant sociability deficits in adolescent mice. Autism Res. 2011 Feb;4(1):17–27. doi: 10.1002/aur.163. X-120928844
894 Yasuda Y, Hashimoto R, Yamamori H, . Gene expression analysis in lymphoblasts derived from patients with autism spectrum disorder. Mol Autism. 2011;2(1):9. doi: 10.1186/2040-2392-2-9. X-121615902
895 Yazawa M, Hsueh B, Jia X, . Using induced pluripotent stem cells to investigate cardiac phenotypes in Timothy syndrome. Nature. 2011 Mar 10;471(7337):230–4. doi: 10.1038/nature09855. X-121307850
896 Zachor DA, Ben Itzchak E. Assisted reproductive technology and risk for autism spectrum disorder. Res Dev Disabil. 2011 Nov–Dec;32(6):2950–6. doi: 10.1016/j.ridd.2011.05.007. X-121658904
897 Zayat M, Kalb L, Wodka E. Brief Report: Performance Pattern Differences Between Children with Autism Spectrum Disorders and Attention Deficit-Hyperactivity Disorder on Measures of Verbal Intelligence. Journal of Autism & Developmental Disorders. 2011;41(12):1743–7 5p. doi: 10.1007/s10803-011-1207-z. Language: English. Entry Date: 20111212. Revision Date: 20150711. Publication Type: Journal Article. X-121360020
898 Zeiner P, Gjevik E, Weidle B. Response to atomoxetine in boys with high-functioning autism spectrum disorders and attention deficit/hyperactivity disorder. Acta Paediatr. 2011 Sep;100(9):1258–61. doi: 10.1111/j.1651-2227.2011.02263.x. X-3, X-421392103
899 Zhu H, Sun Y, Zeng J, . Mirror neural training induced by virtual reality in brain-computer interfaces may provide a promising approach for the autism therapy. Med Hypotheses. 2011 May;76(5):646–7. doi: 10.1016/j.mehy.2011.01.022. X-1, X-2, X-3, X-421300442
900 Trialing targeted therapies for autism. Nat Med. 2012 Dec;18(12):1746–7. doi: 10.1038/nm.3027. X-123223062
901 Improving support for staff and patients with Asperger’s syndrome. Nurs Stand. 2012 Oct 10–16;27(6):63. doi: 10.7748/ns2012.10.27.6.63.p9616. X-1
902 DIGEST. Adapted Physical Activity Quarterly. 2012;29(3):281–5 5p. Language: English. Entry Date: 20120705. Revision Date: 20150819. Publication Type: Journal Article. Journal Subset: Allied Health. X-1
903 NEWS IN BRIEF. ASHA Leader. 2012;17(6):3- 1p. Language: English. Entry Date: 20120520. Revision Date: 20150712. Publication Type: Journal Article. X-1, X-2
904 Abstracts 16/3. Autism: The International Journal of Research & Practice. 2012;16(3):328–31 4p. doi: 10.1177/1362361312441427. Language: English. Entry Date: 20120705. Revision Date: 20150711. Publication Type: Journal Article. X-1, X-2
905 Standing while learning: a clinical case presentation utilizing a standing desk for a student with educational and postural challenges. Pediatric Physical Therapy. 2012 2012 Spring;24(1):109- 1p. Language: English. Entry Date: 20120406. Revision Date: 20150712. Publication Type: Journal Article. X-1, X-2
906 PATIENT INFORMATION SHEET: Risperidone (generic) Risperdal (brand). Brown University Child & Adolescent Psychopharmacology Update. 2012;14:1–2 p. Language: English. Entry Date: 20120904. Revision Date: 20150711. Publication Type: Journal Article. X-1, X-2
907 Significant publication bias found in autism research on repetitive behaviors. Brown University Child & Adolescent Behavior Letter. 2012;28(9):4–5 2p. Language: English. Entry Date: 20120824. Revision Date: 20150711. Publication Type: Journal Article. Journal Subset: Biomedical. X-1, X-2
908 Risperidone may improve maladaptive behaviors in autism. Brown University Child & Adolescent Psychopharmacology Update. 2012;14(9):8- 1p. Language: English. Entry Date: 20120904. Revision Date: 20150711. Publication Type: Journal Article. X-1, X-2
909 Celecoxib added to risperidone effective for autism. Brown University Child & Adolescent Psychopharmacology Update. 2012;14(8):8- 1p. Language: English. Entry Date: 20120827. Revision Date: 20150711. Publication Type: Journal Article. X-1, X-2
910 Autism: Fatty acids may improve social interaction. Brown University Child & Adolescent Psychopharmacology Update. 2012;14(6):7- 1p. Language: English. Entry Date: 20120625. Revision Date: 20150711. Publication Type: Journal Article. X-1, X-2
911 Parent training in combination with risperidone shows benefit. Brown University Child & Adolescent Psychopharmacology Update. 2012;14(3):5- 1p. Language: English. Entry Date: 20120404. Revision Date: 20150711. Publication Type: Journal Article. Journal Subset: Biomedical. X-1, X-2
912 Risperidone and parent training for PDD. Brown University Child & Adolescent Psychopharmacology Update. 2012;14(3):7–8 2p. Language: English. Entry Date: 20120404. Revision Date: 20150711. Publication Type: Journal Article. Journal Subset: Biomedical. X-1, X-2
913 Risperidone linked to incontinence in a child with autism. Brown University Child & Adolescent Psychopharmacology Update. 2012;14(3):8- 1p. Language: English. Entry Date: 20120404. Revision Date: 20150711. Publication Type: Journal Article. X-2, X-3
914 News. Journal of Psychosocial Nursing & Mental Health Services. 2012;50(2):6–43 3p. doi: 10.3928/02793695-20120113-99. Language: English. Entry Date: 20120413. Revision Date: 20150711. Publication Type: Journal Article. X-1, X-2
915 DRUG NEWS. Nursing. 2012;42(2):21- 1p. doi: 10.1097/01.NURSE.0000410316.69228.e9. Language: English. Entry Date: 20120227. Revision Date: 20150712. Publication Type: Journal Article. X-1, X-222157903
916 Intramuscular paliperidone in a young autistic boy with aggression. Brown University Child & Adolescent Psychopharmacology Update. 2012;14(1):8- 1p. Language: English. Entry Date: 20120410. Revision Date: 20150711. Publication Type: Journal Article. X-1, X-2, X-3, X-4
917 Abdallah MW, Hougaard DM, Norgaard-Pedersen B, . Infections during pregnancy and after birth, and the risk of autism spectrum disorders: a register-based study utilizing a Danish historic birth cohort. Turk Psikiyatri Derg. 2012 Winter;23(4):229–35. X-123225123
918 Abu Shmais GA, Al-Ayadhi LY, Al-Dbass AM, . Mechanism of nitrogen metabolism-related parameters and enzyme activities in the pathophysiology of autism. J Neurodev Disord. 2012;4(1):4. doi: 10.1186/1866-1955-4-4. X-122958401
919 Ackerman S, Reilly B, Bernier R. Tympanostomy tube placement in children with autism. J Dev Behav Pediatr. 2012 Apr;33(3):252–8. doi: 10.1097/DBP.0b013e31824b9f57. X-122343482
920 Adams C, Lockton E, Freed J, . The Social Communication Intervention Project: a randomized controlled trial of the effectiveness of speech and language therapy for school-age children who have pragmatic and social communication problems with or without autism spectrum disorder. Int J Lang Commun Disord. 2012 May–Jun;47(3):233–44. doi: 10.1111/j.1460-6984.2011.00146.x. X-122512510
921 Adkins KW, Molloy C, Weiss SK, . Effects of a standardized pamphlet on insomnia in children with autism spectrum disorders. Pediatrics. 2012 Nov;130(Suppl 2):S139–44. doi: 10.1542/peds.2012-0900K. X-123118244
922 Adluru N, Ennis CM, Davidson RJ, . Max Margin General Linear Modeling for Neuroimage Analyses. Proc Workshop Math Methods Biomed Image Analysis. 2012 Jan 10;2012 doi: 10.1109/mmbia.2012.6164735. X-1
923 Ahmedani BK, Hock RM. Health care access and treatment for children with co-morbid autism and psychiatric conditions. Soc Psychiatry Psychiatr Epidemiol. 2012 Nov;47(11):1807–14. doi: 10.1007/s00127-012-0482-0. X-122322982
924 Albores-Gallo L, Roldan-Ceballos O, Villarreal-Valdes G, . M-CHAT Mexican Version Validity and Reliability and Some Cultural Considerations. ISRN Neurol. 2012;2012:408694. doi: 10.5402/2012/408694. X-122811934
925 Alcantara JI, Cope TE, Cope W, . Auditory temporal-envelope processing in high-functioning children with Autism Spectrum Disorder. Neuropsychologia. 2012 Jun;50(7):1235–51. doi: 10.1016/j.neuropsychologia.2012.01.034. X-122349444
926 Aldred C, Green J, Emsley R, . Brief report: mediation of treatment effect in a communication intervention for pre-school children with autism. J Autism Dev Disord. 2012 Mar;42(3):447–54. doi: 10.1007/s10803-011-1248-3. X-1, X-221512834
927 Allison J, Wilder DA, Chong I, . A comparison of differential reinforcement and noncontingent reinforcement to treat food selectivity in a child with autism. J Appl Behav Anal. 2012 Fall;45(3):613–7. doi: 10.1901/jaba.2012.45-613. X-1, X-3, X-423060675
928 Allman MJ, Meck WH. Pathophysiological distortions in time perception and timed performance. Brain: A Journal of Neurology. 2012;135(3):656–77 22p. Language: English. Entry Date: 20120420. Revision Date: 20150711. Publication Type: Journal Article. X-121921020
929 Altenmuller E, Demorest SM, Fujioka T, . Introduction to The neurosciences and music IV: learning and memory. Ann N Y Acad Sci. 2012 Apr;1252:1–16. doi: 10.1111/j.1749-6632.2012.06474.x. X-1
930 Ameis SH, Szatmari P. Imaging-genetics in autism spectrum disorder: advances, translational impact, and future directions. Front Psychiatry. 2012;3:46. doi: 10.3389/fpsyt.2012.00046. X-122615702
931 Amodeo DA, Jones JH, Sweeney JA, . Differences in BTBR T+ tf/J and C57BL/6J mice on probabilistic reversal learning and stereotyped behaviors. Behav Brain Res. 2012 Feb 1;227(1):64–72. doi: 10.1016/j.bbr.2011.10.032. X-122056750
932 Anagnostou E, Soorya L, Chaplin W, . Intranasal oxytocin versus placebo in the treatment of adults with autism spectrum disorders: a randomized controlled trial. Mol Autism. 2012;3(1):16. doi: 10.1186/2040-2392-3-16. X-123216716
933 Anitha A, Nakamura K, Thanseem I, . Brain region-specific altered expression and association of mitochondria-related genes in autism. Mol Autism. 2012;3(1):12. doi: 10.1186/2040-2392-3-12. X-123116158
934 Anonymous F. Sam’s transition story. Narrat Inq Bioeth. 2012 Winter;2(3):179–81. doi: 10.1353/nib.2012.0075. X-124406885
935 Anonymous O. My son’s life with autistic spectrum disorder. Narrat Inq Bioeth. 2012 Winter;2(3):151–3. doi: 10.1353/nib.2012.0063. X-124406874
936 Anonymous T. “Call me ‘he’”: on the relationship between autism, gender, and authenticity. Narrat Inq Bioeth. 2012 Winter;2(3):153–6. doi: 10.1353/nib.2012.0066. X-124406875
937 Anonymous T. Life: one step at a time. Narrat Inq Bioeth. 2012 Winter;2(3):159–61. doi: 10.1353/nib.2012.0072. X-124406877
938 Arnold LE. [Commentary on] Atomoxetine reduces ADHD symptoms in children with autism spectrum disorder. Evidence Based Mental Health. 2012;15(4):96- 1p. Language: English. Entry Date: 20121107. Revision Date: 20150711. Publication Type: Journal Article. X-1, X-223002102
939 Arnold LE, Aman MG, Hollway J, . Placebo-controlled pilot trial of mecamylamine for treatment of autism spectrum disorders. J Child Adolesc Psychopharmacol. 2012 Jun;22(3):198–205. doi: 10.1089/cap.2011.0056.22537359
940 Arnold LE, Aman MG, Li X. Effect of parent training with meds for autism weakens over time. Brown University Child & Adolescent Psychopharmacology Update. 2012;14(12):1–3 p. Language: English. Entry Date: 20121203. Revision Date: 20150711. Publication Type: Journal Article. Journal Subset: Biomedical. X-1, X-2
941 Arnold LE, Aman MG, Li X, . Research Units of Pediatric Psychopharmacology (RUPP) autism network randomized clinical trial of parent training and medication: one-year follow-up. J Am Acad Child Adolesc Psychiatry. 2012 Nov;51(11):1173–84. doi: 10.1016/j.jaac.2012.08.028. X-123101743
942 Arnold LE, Farmer CA, Aman M, . Points for practitioners. Brown University Child & Adolescent Psychopharmacology Update. 2012;14(1):3- 1p. Language: English. Entry Date: 20120410. Revision Date: 20150711. Publication Type: Journal Article. X-1, X-2
943 Asada K, Itakura S. Social phenotypes of autism spectrum disorders and williams syndrome: similarities and differences. Front Psychol. 2012;3:247. doi: 10.3389/fpsyg.2012.00247. X-122866045
944 Assouline S, Foley Nicpon M, Dockery L. Predicting the Academic Achievement of Gifted Students with Autism Spectrum Disorder. Journal of Autism & Developmental Disorders. 2012;42(9):1781–9 9p. doi: 10.1007/s10803-011-1403-x. Language: English. Entry Date: 20120824. Revision Date: 20150711. Publication Type: Journal Article. X-122105142
945 Atladottir HO, Henriksen TB, Schendel DE, . Autism after infection, febrile episodes, and antibiotic use during pregnancy: an exploratory study. Pediatrics. 2012 Dec;130(6):e1447–54. doi: 10.1542/peds.2012-1107. X-123147969
946 Atzori M, Garcia-Oscos F, Mendez JA. Role of IL-6 in the etiology of hyperexcitable neuropsychiatric conditions: experimental evidence and therapeutic implications. Future Med Chem. 2012 Nov;4(17):2177–92. doi: 10.4155/fmc.12.156. X-123190106
947 Auert EJ, Trembath D, Arciuli J, . Parents’ expectations, awareness, and experiences of accessing evidence-based speech-language pathology services for their children with autism. Int J Speech Lang Pathol. 2012 Apr;14(2):109–18. doi: 10.3109/17549507.2011.652673. X-122390744
948 Ayaz M, Ayaz AB, Basgul SS, . Prevelance of mental disorders and associated factors in institutionalized 3–5 year old children. Turk Psikiyatri Derg. 2012 Summer;23(2):82–8. X-122648870
949 Ayuda-Pascual R, Llorente-Comi M, Martos-Perez J, . [Measurements of stress and family impact in the parents of children with autism spectrum disorders before and after taking part in a training programme]. Rev Neurol. 2012 Feb 29;54(Suppl 1):S73–80. X-1, X-322374775
950 Babineau BA, Yang M, Crawley JN. Mainstreaming mice. Neuropsychopharmacology. 2012 Jan;37(1):300–1. doi: 10.1038/npp.2011.168. X-122157866
951 Baez S, Rattazzi A, Gonzalez-Gadea ML, . Integrating intention and context: assessing social cognition in adults with Asperger syndrome. Front Hum Neurosci. 2012;6:302. doi: 10.3389/fnhum.2012.00302. X-123162450
952 Bagni C, Tassone F, Neri G, . Fragile X syndrome: causes, diagnosis, mechanisms, and therapeutics. J Clin Invest. 2012 Dec;122(12):4314–22. doi: 10.1172/jci63141. X-123202739
953 Bahrami F, Movahedi A, Marandi SM, . Kata techniques training consistently decreases stereotypy in children with autism spectrum disorder. Res Dev Disabil. 2012 Jul–Aug;33(4):1183–93. doi: 10.1016/j.ridd.2012.01.018. X-122502844
954 Barnes RE, McCabe H. Should we welcome a cure for autism? A survey of the arguments. Med Health Care Philos. 2012 Aug;15(3):255–69. doi: 10.1007/s11019-011-9339-7. X-121837546
955 Bazzano A, Zeldin A, Schuster E, . Vaccine-related beliefs and practices of parents of children with autism spectrum disorders. Am J Intellect Dev Disabil. 2012 May;117(3):233–42. doi: 10.1352/1944-7558-117.3.233. X-222716265
956 Ben Said M, Robel L, Pellegrin-Touati M, . TEDIS, Pervasive Developmental Disorder’ patients information system, preliminary results. Stud Health Technol Inform. 2012;180:285–9. X-122874197
957 Bent S, Bertoglio K, Ashwood P, . Brief report: Hyperbaric oxygen therapy (HBOT) in children with autism spectrum disorder: a clinical trial. J Autism Dev Disord. 2012 Jun;42(6):1127–32. doi: 10.1007/s10803-011-1337-3. X-3, X-421818676
958 Bergstrom R, Najdowski AC, Tarbox J. Teaching children with autism to seek help when lost in public. J Appl Behav Anal. 2012 Spring;45(1):191–5. doi: 10.1901/jaba.2012.45-191. X-1, X-3, X-422403465
959 Bett GC, Lis A, Wersinger SR, . A Mouse Model of Timothy Syndrome: a Complex Autistic Disorder Resulting from a Point Mutation in Cav1.2. N Am J Med Sci (Boston). 2012 Jul 25;5(3):135–40. X-124371506
960 Bevan Jones R, Thapar A, Lewis G, . The association between early autistic traits and psychotic experiences in adolescence. Schizophr Res. 2012 Mar;135(1–3):164–9. doi: 10.1016/j.schres.2011.11.037. X-122245185
961 Bilbo SD, Jones JP, Parker W. Is autism a member of a family of diseases resulting from genetic/cultural mismatches? Implications for treatment and prevention. Autism Res Treat. 2012;2012:910946. doi: 10.1155/2012/910946. X-122928103
962 Blanche EI, Reinoso G, Chang MC, . Proprioceptive processing difficulties among children with autism spectrum disorders and developmental disabilities. American Journal of Occupational Therapy. 2012 2015-12-09;66(5):621–4. doi: http://dx.doi.org/10.5014/ajot.2012.004234; 2012-25996-013. X-122917129
963 Blaucok-Busch E, Amin OR, Dessoki HH, . Efficacy of DMSA Therapy in a Sample of Arab Children with Autistic Spectrum Disorder. Maedica (Buchar). 2012 Sep;7(3):214–21. X-123400264
964 Bodner KE, Beversdorf DQ, Saklayen SS, . Noradrenergic moderation of working memory impairments in adults with autism spectrum disorder. J Int Neuropsychol Soc. 2012 May;18(3):556–64. doi: 10.1017/s1355617712000070. X-122414705
965 Boisvert M, Hall N, Andrianopoulos M, . The Multi-faceted Implementation of Telepractice to Service Individuals with Autism. Int J Telerehabil. 2012 Fall;4(2):11–24. doi: 10.5195/ijt.2012.6104. X-125945200
966 Bolduc ME, du Plessis AJ, Sullivan N, . Regional cerebellar volumes predict functional outcome in children with cerebellar malformations. Cerebellum. 2012 Jun;11(2):531–42. doi: 10.1007/s12311-011-0312-z. X-121901523
967 Borthwick L. Adulthood: Life lessons. Nature. 2012 Nov 1;491(7422):S10–1. X-123136653
968 Bou Khalil R. Would some cannabinoids ameliorate symptoms of autism? Eur Child Adolesc Psychiatry. 2012 Apr;21(4):237–8. doi: 10.1007/s00787-012-0255-z. X-222350104
969 Bourret JC, Iwata BA, Harper JM, . Elimination of position-biased responding in individuals with autism and intellectual disabilities. J Appl Behav Anal. 2012 Summer;45(2):241–50. doi: 10.1901/jaba.2012.45-241. X-122844134
970 Bourzac K. Child development: The first steps. Nature. 2012 Nov 1;491(7422):S7–9. X-123136652
971 Brady NC, Anderson CJ, Hahn LJ, . Eye Tracking as a Measure of Receptive Vocabulary in Children with Autism Spectrum Disorders. AAC: Augmentative & Alternative Communication. 2012;30(2):147–59 13p. doi: 10.3109/07434618.2014.904923. Language: English. Entry Date: 20140620. Revision Date: 20150819. Publication Type: Journal Article. X-1
972 Bransfield RC. The psychoimmunology of lyme/tick-borne diseases and its association with neuropsychiatric symptoms. Open Neurol J. 2012;6:88–93. doi: 10.2174/1874205x01206010088. X-123091569
973 Brookman-Frazee L, Baker-Ericzen M, Stadnick N, . Parent Perspectives on Community Mental Health Services for Children with Autism Spectrum Disorders. J Child Fam Stud. 2012 Aug 1;21(4)doi: 10.1007/s10826-011-9506-8. X-1
974 Brookman-Frazee L, Drahota A, Stadnick N, . Therapist perspectives on community mental health services for children with autism spectrum disorders. Adm Policy Ment Health. 2012 Sep;39(5):365–73. doi: 10.1007/s10488-011-0355-y. X-121533846
975 Brookman-Frazee LI, Drahota A, Stadnick N. Training community mental health therapists to deliver a package of evidence-based practice strategies for school-age children with autism spectrum disorders: a pilot study. J Autism Dev Disord. 2012 Aug;42(8):1651–61. doi: 10.1007/s10803-011-1406-7. X-3, X-422102293
976 Brown HK, Ouellette-Kuntz H, Hunter D, . Unmet needs of families of school-aged children with an autism spectrum disorder. J Appl Res Intellect Disabil. 2012 Nov;25(6):497–508. doi: 10.1111/j.1468-3148.2012.00692.x. X-123055284
977 Brown KF, Long SJ, Ramsay M, . U.K. parents’ decision-making about measles-mumps-rubella (MMR) vaccine 10 years after the MMR-autism controversy: a qualitative analysis. Vaccine. 2012 Feb 27;30(10):1855–64. doi: 10.1016/j.vaccine.2011.12.127. X-122230590
978 Buchbinder M. “Sticky” brains and sticky encounters in a U.S. pediatric pain clinic. Cult Med Psychiatry. 2012 Mar;36(1):102–23. doi: 10.1007/s11013-011-9237-8. X-122006075
979 Busnelli M, Sauliere A, Manning M, . Functional selective oxytocin-derived agonists discriminate between individual G protein family subtypes. J Biol Chem. 2012 Feb 3;287(6):3617–29. doi: 10.1074/jbc.M111.277178. X-122069312
980 Butler MG, Youngs EL, Roberts JL, . Assessment and treatment in autism spectrum disorders: a focus on genetics and psychiatry. Autism Res Treat. 2012;2012:242537. doi: 10.1155/2012/242537. X-122934170
981 Buxbaum JD, Betancur C, Bozdagi O, . Optimizing the phenotyping of rodent ASD models: enrichment analysis of mouse and human neurobiological phenotypes associated with high-risk autism genes identifies morphological, electrophysiological, neurological, and behavioral features. Mol Autism. 2012;3(1):1. doi: 10.1186/2040-2392-3-1. X-122348382
982 Campbell D, Love E, Crum J, . PP142. Independent effects of pregnancy induced hypertension on childhood development: A retrospective cohort study. Pregnancy Hypertens. 2012 Jul;2(3):316. doi: 10.1016/j.preghy.2012.04.253. X-126105463
983 Capozza LE, Bimstein E. Preferences of parents of children with autism spectrum disorders concerning oral health and dental treatment. Pediatr Dent. 2012 Nov–Dec;34(7):480–4. X-123265165
984 Carp CL, Peterson SP, Arkel AJ, . A further evaluation of picture prompts during auditory-visual conditional discrimination training. J Appl Behav Anal. 2012 Winter;45(4):737–51. doi: 10.1901/jaba.2012.45-737. X-3, X-423322929
985 Carrasco M, Volkmar FR. Significant publication bias found in research on repetitive behaviors. Brown University Child & Adolescent Psychopharmacology Update. 2012;14(6):1–4 p. doi: 10.1542/peds.2011-3285. Language: English. Entry Date: 20120625. Revision Date: 20150711. Publication Type: Journal Article. Journal Subset: Biomedical. X-1
986 Casanova MF, Baruth JM, El-Baz A, . Repetitive Transcranial Magnetic Stimulation (rTMS) Modulates Event-Related Potential (ERP) Indices of Attention in Autism. Transl Neurosci. 2012 Jun 1;3(2):170–80. doi: 10.2478/s13380-012-0022-0. X-124683490
987 Cascio CJ, Foss-Feig JH, Heacock JL, . Response of neural reward regions to food cues in autism spectrum disorders. J Neurodev Disord. 2012;4(1):9. doi: 10.1186/1866-1955-4-9. X-122958533
988 Cavalari RN, Romanczyk RG. Caregiver perspectives on unintentional injury risk in children with an autism spectrum disorder. J Pediatr Nurs. 2012 Dec;27(6):632–41. doi: 10.1016/j.pedn.2011.07.013. X-123101727
989 Cebula KR. Applied behavior analysis programs for autism: sibling psychosocial adjustment during and following intervention use. J Autism Dev Disord. 2012 May;42(5):847–62. doi: 10.1007/s10803-011-1322-x. X-121725720
990 Centineo L. Above the noise and confusion. Narrat Inq Bioeth. 2012 Winter;2(3):156–9. doi: 10.1353/nib.2012.0069. X-124406876
991 Chan AS, Sze SL, Han YM, . A chan dietary intervention enhances executive functions and anterior cingulate activity in autism spectrum disorders: a randomized controlled trial. Evid Based Complement Alternat Med. 2012;2012:262136. doi: 10.1155/2012/262136. X-122666288
992 Chan AW, Kocerha J. The Path to microRNA Therapeutics in Psychiatric and Neurodegenerative Disorders. Front Genet. 2012;3:82. doi: 10.3389/fgene.2012.00082. X-122629284
993 Chang MC, Parham LD, Blanche EI, . Autonomic and behavioral responses of children with autism to auditory stimuli. Am J Occup Ther. 2012 Sep–Oct;66(5):567–76. doi: 10.5014/ajot.2012.004242. X-1, X-322917123
994 Chen GM, Yoder KJ, Ganzel BL, . Harnessing repetitive behaviours to engage attention and learning in a novel therapy for autism: an exploratory analysis. Front Psychol. 2012;3:12. doi: 10.3389/fpsyg.2012.00012. X-3, X-422355292
995 Cheng Y, Huang R. Using virtual reality environment to improve joint attention associated with pervasive developmental disorder. Res Dev Disabil. 2012 Nov–Dec;33(6):2141–52. doi: 10.1016/j.ridd.2012.05.023. X-1, X-322776822
996 Chester VL, Calhoun M. Gait symmetry in children with autism. Autism Res Treat. 2012;2012:576478. doi: 10.1155/2012/576478. X-122934175
997 Chez M, Low R, Parise C, . Safety and observations in a pilot study of lenalidomide for treatment in autism. Autism Res Treat. 2012;2012:291601. doi: 10.1155/2012/291601. X-322997574
998 Ching H, Pringsheim T. Aripiprazole for autism spectrum disorders (ASD). Cochrane Database of Systematic Reviews. 2012(5):N.PAG-N.PAG 1p. Language: English. Entry Date: 20101029. Revision Date: 20150712. Publication Type: Journal Article. X-2
999 Chiri G, Warfield ME. Unmet need and problems accessing core health care services for children with autism spectrum disorder. Matern Child Health J. 2012 Jul;16(5):1081–91. doi: 10.1007/s10995-011-0833-6. X-121667201
1000 Christophersen OA. Should autism be considered a canary bird telling that Homo sapiens may be on its way to extinction? Microb Ecol Health Dis. 2012;23 doi: 10.3402/mehd.v23i0.19008. X-1
1001 Cihak DF, Kildare LK, Smith CC, . Using video Social Stories to increase task engagement for middle school students with autism spectrum disorders. Behav Modif. 2012 May;36(3):399–425. doi: 10.1177/0145445512442683. X-3, X-422609764
1002 Cimera RE, Wehman P, West M, . Do sheltered workshops enhance employment outcomes for adults with autism spectrum disorder? Autism. 2012 Jan;16(1):87–94. doi: 10.1177/1362361311408129. X-121610189
1003 Cocchiola MA, Jr., Martino GM, Dwyer LJ, . Toilet training children with autism and developmental delays: an effective program for school settings. Behav Anal Pract. 2012 Winter;5(2):60–4. X-1, X-3, X-423730467
1004 Cohen-Ophir M, Castel-Deutsh T, Tirosh E. Autism in early childhood: an unusual developmental course-three case reports. Case Rep Psychiatry. 2012;2012:946109. doi: 10.1155/2012/946109. X-1, X-322937419
1005 Colon CL, Ahearn WH, Clark KM, . The effects of verbal operant training and response interruption and redirection on appropriate and inappropriate vocalizations. J Appl Behav Anal. 2012 Spring;45(1):107–20. doi: 10.1901/jaba.2012.45-107. X-3, X-422403453
1006 Constable PA, Gaigg SB, Bowler DM, . Motion and pattern cortical potentials in adults with high-functioning autism spectrum disorder. Doc Ophthalmol. 2012 Aug 25 doi: 10.1007/s10633-012-9349-7. X-1
1007 Constantine RJ, Jentz S, Bengtson M, . Exposure to antipsychotic medications over a 4-year period among children who initiated antipsychotic treatment before their sixth birthday. Pharmacoepidemiol Drug Saf. 2012 Feb;21(2):152–60. doi: 10.1002/pds.2189. X-1, X-321793097
1008 Coo H, Ouellette-Kuntz H, Lam M, . Correlates of age at diagnosis of autism spectrum disorders in six Canadian regions. Chronic Dis Inj Can. 2012 Mar;32(2):90–100. X-122414306
1009 Corbett BA, Schupp CW, Lanni KE. Comparing biobehavioral profiles across two social stress paradigms in children with and without autism spectrum disorders. Mol Autism. 2012;3(1):13. doi: 10.1186/2040-2392-3-13. X-123158965
1010 Cornell C. Health care disparities: not just for the physically disabled. Narrat Inq Bioeth. 2012 Winter;2(3):163–5. doi: 10.1353/nib.2012.0076. X-124406879
1011 Cornell C. Transition years: from learning, living and loving to maintenance and mediocrity. Narrat Inq Bioeth. 2012 Winter;2(3):E1–3. doi: 10.1353/nib.2012.0077. X-1
1012 Cornish K, Cole V, Longhi E, . Does attention constrain developmental trajectories in fragile x syndrome? A 3-year prospective longitudinal study. Am J Intellect Dev Disabil. 2012 Mar;117(2):103–20. doi: 10.1352/1944-7558-117.2.103. X-122515826
1013 Cortesi F, Giannotti F, Sebastiani T, . Controlled-release melatonin, singly and combined with cognitive behavioural therapy, for persistent insomnia in children with autism spectrum disorders: a randomized placebo-controlled trial. J Sleep Res. 2012 Dec;21(6):700–9. doi: 10.1111/j.1365-2869.2012.01021.x.22616853
1014 Costigan FA, Light JC, Newell KM. Factors affecting computer mouse use for young children: implications for AAC. Augment Altern Commun. 2012 Jun;28(2):85–95. doi: 10.3109/07434618.2012.679235. X-122670726
1015 Coury DL, Anagnostou E, Manning-Courtney P, . Use of psychotropic medication in children and adolescents with autism spectrum disorders. Pediatrics. 2012 Nov;130(Suppl 2):S69–76. doi: 10.1542/peds.2012-0900D. X-1, X-323118256
1016 Cox DJ. From interdisciplinary to integrated care of the child with autism: the essential role for a code of ethics. J Autism Dev Disord. 2012 Dec;42(12):2729–38. doi: 10.1007/s10803-012-1530-z. X-122527703
1017 Cox N, Reeve R, Cox S, . Brief Report: Driving and Young Adults with ASD: Parents’ Experiences. Journal of Autism & Developmental Disorders. 2012;42(10):2257–62 6p. doi: 10.1007/s10803-012-1470-7. Language: English. Entry Date: 20120925. Revision Date: 20150711. Publication Type: Journal Article. X-122359179
1018 Crespi BJ, Crofts HJ. Association testing of copy number variants in schizophrenia and autism spectrum disorders. J Neurodev Disord. 2012;4(1):15. doi: 10.1186/1866-1955-4-15. X-122958593
1019 Cummings C. Melatonin for the management of sleep disorders in children and adolescents. Paediatr Child Health. 2012 Jun;17(6):331–6. X-123730172
1020 Cunningham AB. Measuring change in social interaction skills of young children with autism. J Autism Dev Disord. 2012 Apr;42(4):593–605. doi: 10.1007/s10803-011-1280-3. X-121638109
1021 D’Alessandro TMM. Low-dose AbilifyRTM and the treatment of disruptive behaviors in children with autism spectrum disorders: University of Florida; 2012.
1022 Damiano CR, Aloi J, Treadway M, . Adults with autism spectrum disorders exhibit decreased sensitivity to reward parameters when making effort-based decisions. J Neurodev Disord. 2012;4(1):13. doi: 10.1186/1866-1955-4-13. X-122958545
1023 Danesh AA, Kaf WA. DPOAEs and contralateral acoustic stimulation and their link to sound hypersensitivity in children with autism. Int J Audiol. 2012 Apr;51(4):345–52. doi: 10.3109/14992027.2011.626202. X-122299666
1024 Dannemiller L, LaVesser P, Kinsey E, . Timing and rhythmicity intervention for motor impairments in children with autism spectrum disorder. Pediatric Physical Therapy. 2012 2012 Winter;24(4):372- 1p. Language: English. Entry Date: 20121207. Revision Date: 20150712. Publication Type: Journal Article. X-5
1025 David FJ, Baranek GT, Wiesen C, . Coordination of precision grip in 2–6 years-old children with autism spectrum disorders compared to children developing typically and children with developmental disabilities. Front Integr Neurosci. 2012;6:122. doi: 10.3389/fnint.2012.00122. X-123293589
1026 Dawson G, Bernier R, Ring RH. Social attention: a possible early indicator of efficacy in autism clinical trials. J Neurodev Disord. 2012;4(1):11. doi: 10.1186/1866-1955-4-11. X-1, X-222958480
1027 Dawson G, Jones EJ, Merkle K, . Early behavioral intervention is associated with normalized brain activity in young children with autism. J Am Acad Child Adolesc Psychiatry. 2012 Nov;51(11):1150–9. doi: 10.1016/j.jaac.2012.08.018. X-123101741
1028 De Andres-Garcia S, Moya-Albiol L, Gonzalez-Bono E. Salivary cortisol and immunoglobulin A: responses to stress as predictors of health complaints reported by caregivers of offspring with autistic spectrum disorder. Horm Behav. 2012 Sep;62(4):464–74. doi: 10.1016/j.yhbeh.2012.08.003. X-122981424
1029 de Araujo AN, de Sena EP, de Oliveira IR, . Antipsychotic agents: efficacy and safety in schizophrenia. Drug Healthc Patient Saf. 2012;4:173–80. doi: 10.2147/dhps.s37429. X-123236256
1030 de Bruin EI, Verheij F. Social skills training in children with PDD-NOS: an exploratory study. Int J Psychiatry Clin Pract. 2012 Mar;16(1):60–7. doi: 10.3109/13651501.2011.617455. X-3, X-422122657
1031 Delmonte S, Balsters JH, McGrath J, . Social and monetary reward processing in autism spectrum disorders. Mol Autism. 2012;3(1):7. doi: 10.1186/2040-2392-3-7. X-1, X-323014171
1032 Depape AM, Chen A, Hall GB, . Use of prosody and information structure in high functioning adults with autism in relation to language ability. Front Psychol. 2012;3:72. doi: 10.3389/fpsyg.2012.00072. X-122470358
1033 DePape AM, Hall GB, Tillmann B, . Auditory processing in high-functioning adolescents with Autism Spectrum Disorder. PLoS One. 2012;7(9):e44084. doi: 10.1371/journal.pone.0044084. X-122984462
1034 Desai MU, Divan G, Wertz FJ, . The discovery of autism: Indian parents’ experiences of caring for their child with an autism spectrum disorder. Transcult Psychiatry. 2012 Jul;49(3–4):613–37. doi: 10.1177/1363461512447139. X-122722980
1035 Deutsch SI, Pepe GJ, Burket JA, . D-cycloserine improves sociability and spontaneous stereotypic behaviors in 4-week old mice. Brain Res. 2012 Feb 23;1439:96–107. doi: 10.1016/j.brainres.2011.12.040. X-122261249
1036 Dichter GS, Damiano CA, Allen JA. Reward circuitry dysfunction in psychiatric and neurodevelopmental disorders and genetic syndromes: animal models and clinical findings. J Neurodev Disord. 2012;4(1):19. doi: 10.1186/1866-1955-4-19. X-122958744
1037 Diehl JJ, Paul R. Acoustic Differences In The Imitation Of Prosodic Patterns In Children With Autism Spectrum Disorders. Res Autism Spectr Disord. 2012 Jan;6(1):123–34. doi: 10.1016/j.rasd.2011.03.012. X-122125576
1038 Diehl JJ, Schmitt LM, Villano M, . The Clinical Use of Robots for Individuals with Autism Spectrum Disorders: A Critical Review. Res Autism Spectr Disord. 2012 Jan;6(1):249–62. doi: 10.1016/j.rasd.2011.05.006. X-1, X-222125579
1039 Dineen K, Bultas M. Introduction: parenting children with autism spectrum disorders during the transition to adulthood. Narrat Inq Bioeth. 2012 Winter;2(3):147–9. doi: 10.1353/nib.2012.0061. X-124406872
1040 Divan G, Vajaratkar V, Desai MU, . Challenges, coping strategies, and unmet needs of families with a child with autism spectrum disorder in Goa, India. Autism Res. 2012 Jun;5(3):190–200. doi: 10.1002/aur.1225. X-122473816
1041 Donohue SE, Darling EF, Mitroff SR. Links between multisensory processing and autism. Exp Brain Res. 2012 Oct;222(4):377–87. doi: 10.1007/s00221-012-3223-4. X-122923209
1042 Dove D, Warren Z, McPheeters ML. Evidence on medication treatment for autism lacking. Brown University Child & Adolescent Psychopharmacology Update. 2012;14(12):5- 1p. Language: English. Entry Date: 20121203. Revision Date: 20150711. Publication Type: Journal Article. X-1, X-2
1043 Dove D, Warren Z, McPheeters ML, . Medications for Adolescents and Young Adults With Autism Spectrum Disorders: A Systematic Review. Pediatrics. 2012;130(4):717–26 10p. doi: 10.1542/Deds.2012-0683. Language: English. Entry Date: 20121004. Revision Date: 20150712. Publication Type: Journal Article. X-1, X-223008452
1044 Dowd A, McGinley J, Taffe J, . Do Planning and Visual Integration Difficulties Underpin Motor Dysfunction in Autism? A Kinematic Study of Young Children with Autism. Journal of Autism & Developmental Disorders. 2012;42(8):1539–48 10p. doi: 10.1007/s10803-011-1385-8. Language: English. Entry Date: 20120724. Revision Date: 20150711. Publication Type: Journal Article. X-122105140
1045 Downey R, Rapport MJ. Motor activity in children with autism: a review of current literature. Pediatric Physical Therapy. 2012 2012 Spring;24(1):2–20 19p. Language: English. Entry Date: 20120406. Revision Date: 20150820. Publication Type: Journal Article. X-1, X-222207460
1046 Drahota A, Aarons GA, Stahmer AC. Developing the Autism Model of Implementation for autism spectrum disorder community providers: study protocol. Implement Sci. 2012;7:85. doi: 10.1186/1748-5908-7-85. X-222963616
1047 Ducharme JM, Ng O. Errorless academic compliance training: a school-based application for young students with autism. Behav Modif. 2012 Sep;36(5):650–69. doi: 10.1177/0145445511436006. X-3, X-422421393
1048 Dugger BN, Serrano GE, Sue LI, . Presence of Striatal Amyloid Plaques in Parkinson’s Disease Dementia Predicts Concomitant Alzheimer’s Disease: Usefulness for Amyloid Imaging. J Parkinsons Dis. 2012 Jan 1;2(1):57–65. doi: 10.3233/jpd-2012-11073. X-122924088
1049 Dunbar SB, Carr-Hertesl J, Lieberman HA, . A Pilot Study Comparison of Sensory Integration Treatment and Integrated Preschool Activities for Children with Autism. Internet Journal of Allied Health Sciences & Practice. 2012;10(3):8p-p 1p. Language: English. Entry Date: 20120928. Revision Date: 20150818. Publication Type: Journal Article. X-3
1050 Dunn W, Cox J, Foster L, . Impact of a contextual intervention on child participation and parent competence among children with autism spectrum disorders: a pretest-posttest repeated-measures design. Am J Occup Ther. 2012 Sep–Oct;66(5):520–8. doi: 10.5014/ajot.2012.004119. X-322917118
1051 Dunphy-Lelii S, Wellman HM. Delayed Self Recognition in Autism: A Unique Difficulty? Res Autism Spectr Disord. 2012 Jan;6(1):212–23. doi: 10.1016/j.rasd.2011.05.002. X-122125578
1052 Dunst CJ, Trivette CM, Hamby DW. Meta-analysis of studies incorporating the interests of young children with autism spectrum disorders into early intervention practices. Autism Res Treat. 2012;2012:462531. doi: 10.1155/2012/462531. X-222934173
1053 Dworzynski K, Ronald A, Bolton P, . How different are girls and boys above and below the diagnostic threshold for autism spectrum disorders? J Am Acad Child Adolesc Psychiatry. 2012 Aug;51(8):788–97. doi: 10.1016/j.jaac.2012.05.018. X-122840550
1054 Dykstra JR, Boyd BA, Watson LR, . The impact of the Advancing Social-communication And Play (ASAP) intervention on preschoolers with autism spectrum disorder. Autism. 2012 Jan;16(1):27–44. doi: 10.1177/1362361311408933. X-3, X-421788256
1055 Eisenberg E. Long-term outcomes in children born after assisted conception. Semin Reprod Med. 2012 Apr;30(2):123–30. doi: 10.1055/s-0032-1307420. X-122549712
1056 Eisenstein M. Treatments: In the waiting room. Nature. 2012 Nov 1;491(7422):S14–6. X-223136658
1057 Elbe D, Lalani Z. Review of the pharmacotherapy of irritability of autism. J Can Acad Child Adolesc Psychiatry. 2012 May;21(2):130–46. X-2, X-322548111
1058 Eldevik S, Hastings RP, Jahr E, . Outcomes of behavioral intervention for children with autism in mainstream pre-school settings. J Autism Dev Disord. 2012 Feb;42(2):210–20. doi: 10.1007/s10803-011-1234-9. X-121472360
1059 Ellegood J, Henkelman RM, Lerch JP. Neuroanatomical Assessment of the Integrin beta3 Mouse Model Related to Autism and the Serotonin System Using High Resolution MRI. Front Psychiatry. 2012;3:37. doi: 10.3389/fpsyt.2012.00037. X-1, X-222557981
1060 Emck C, Bosscher RJ, van Wieringen PC, . Psychiatric symptoms in children with gross motor problems. Adapt Phys Activ Q. 2012 Apr;29(2):161–78. X-122467835
1061 Enticott PG, Kennedy HA, Rinehart NJ, . Mirror neuron activity associated with social impairments but not age in autism spectrum disorder. Biol Psychiatry. 2012 Mar 1;71(5):427–33. doi: 10.1016/j.biopsych.2011.09.001. X-121974786
1062 Enticott PG, Rinehart NJ, Tonge BJ, . Repetitive transcranial magnetic stimulation (rTMS) improves movement-related cortical potentials in autism spectrum disorders. Brain Stimul. 2012 Jan;5(1):30–7. doi: 10.1016/j.brs.2011.02.001. X-1, X-3, X-422037133
1063 Eriksson MA, Westerlund J, Anderlid BM, . First-degree relatives of young children with autism spectrum disorders: some gender aspects. Res Dev Disabil. 2012 Sep–Oct;33(5):1642–8. doi: 10.1016/j.ridd.2012.03.025. X-122554810
1064 Eyler LT, Pierce K, Courchesne E. A failure of left temporal cortex to specialize for language is an early emerging and fundamental property of autism. Brain. 2012 Mar;135(Pt 3):949–60. doi: 10.1093/brain/awr364. X-122350062
1065 Faja S, Webb SJ, Jones E, . The effects of face expertise training on the behavioral performance and brain activity of adults with high functioning autism spectrum disorders. J Autism Dev Disord. 2012 Feb;42(2):278–93. doi: 10.1007/s10803-011-1243-8. X-121484517
1066 Falter CM, Noreika V, Wearden JH, . More consistent, yet less sensitive: interval timing in autism spectrum disorders. Q J Exp Psychol (Hove). 2012;65(11):2093–107. doi: 10.1080/17470218.2012.690770. X-122800511
1067 Fan J, Bernardi S, Van Dam NT, . Functional deficits of the attentional networks in autism. Brain Behav. 2012 Sep;2(5):647–60. doi: 10.1002/brb3.90. X-123139910
1068 Farmer C, Lecavalier L, Yu S, . Predictors and moderators of parent training efficacy in a sample of children with autism spectrum disorders and serious behavioral problems. J Autism Dev Disord. 2012 Jun;42(6):1037–44. doi: 10.1007/s10803-011-1338-2. X-121822762
1069 Farrell L, Waters A, Milliner E, . Comorbidity and treatment response in pediatric obsessive-compulsive disorder: a pilot study of group cognitive-behavioral treatment. Psychiatry Res. 2012 Sep 30;199(2):115–23. doi: 10.1016/j.psychres.2012.04.035. X-1, X-3, X-422633155
1070 Feehan K, O’Neil ME, Abdalla D, . Factors influencing physical activity in children and youth with special health care needs: a pilot study. Int J Pediatr. 2012;2012:583249. doi: 10.1155/2012/583249. X-122611411
1071 Felce D, Perry J. Diagnostic grouping among adults with intellectual disabilities and autistic spectrum disorders in staffed housing. J Intellect Disabil Res. 2012 Dec;56(12):1187–93. doi: 10.1111/j.1365-2788.2011.01496.x. X-122044559
1072 Fengler S. [The long way to an emotionally closed off girl]. Kinderkrankenschwester. 2012 Sep;31(9):390–1. X-123016230
1073 Fiksdal BL, Houlihan D, Barnes AC. Dolphin-Assisted Therapy: Claims versus Evidence. Autism Res Treat. 2012;2012:839792. doi: 10.1155/2012/839792. X-222928101
1074 Finn HE, Miguel CF, Ahearn WH. The emergence of untrained mands and tacts in children with autism. J Appl Behav Anal. 2012 Summer;45(2):265–80. doi: 10.1901/jaba.2012.45-265. X-1, X-422844136
1075 Fleischer AS. Support to students with Asperger syndrome in higher education--the perspectives of three relatives and three coordinators. Int J Rehabil Res. 2012 Mar;35(1):54–61. doi: 10.1097/MRR.0b013e32834f4d3b. X-122315142
1076 Fletcher PC, Markoulakis R, Bryden PJ. The costs of caring for a child with an autism spectrum disorder. Issues Compr Pediatr Nurs. 2012;35(1):45–69. doi: 10.3109/01460862.2012.645407. X-122250966
1077 Flores M, Musgrove K, Renner S, . A comparison of communication using the Apple iPad and a picture-based system. Augment Altern Commun. 2012 Jun;28(2):74–84. doi: 10.3109/07434618.2011.644579. X-1, X-3, X-422263895
1078 Fogleman CD. Therapies for children with autism spectrum disorders. Am Fam Physician. 2012 May 1;85(9):878–80. X-222612182
1079 Foley AG, Gannon S, Rombach-Mullan N, . Class I histone deacetylase inhibition ameliorates social cognition and cell adhesion molecule plasticity deficits in a rodent model of autism spectrum disorder. Neuropharmacology. 2012 Sep;63(4):750–60. doi: 10.1016/j.neuropharm.2012.05.042. X-122683514
1080 Forbes D, Parsons H. Essential fatty acids: food for mind and body. Acta Paediatr. 2012 Aug;101(8):808–10. doi: 10.1111/j.1651-2227.2012.02748.x. X-122646925
1081 Foss-Feig JH, Heacock JL, Cascio CJ. TACTILE RESPONSIVENESS PATTERNS AND THEIR ASSOCIATION WITH CORE FEATURES IN AUTISM SPECTRUM DISORDERS. Res Autism Spectr Disord. 2012 Winter;6(1):337–44. doi: 10.1016/j.rasd.2011.06.007. X-122059092
1082 Foster EM, Pearson E. Is inclusivity an indicator of quality of care for children with autism in special education? Pediatrics. 2012 Nov;130(Suppl 2):S179–85. doi: 10.1542/peds.2012-0900P. X-1, X-323118249
1083 Fragale CL, O’Reilly MF, Aguilar J, . The influence of motivating operations on generalization probes of specific mands by children with autism. J Appl Behav Anal. 2012 Fall;45(3):565–77. doi: 10.1901/jaba.2012.45-565. X-1, X-3, X-423060669
1084 François M, Teissier N, Barthod G, . Sedation for children 2 to 5 years of age undergoing auditory brainstem response and auditory steady state responses recordings. International Journal of Audiology. 2012;51(4):282–6 5p. doi: 10.3109/14992027.2011.601469. Language: English. Entry Date: 20120322. Revision Date: 20150820. Publication Type: Journal Article. X-121936745
1085 Freitag CM, Feineis-Matthews S, Valerian J, . The Frankfurt early intervention program FFIP for preschool aged children with autism spectrum disorder: a pilot study. J Neural Transm (Vienna). 2012 Sep;119(9):1011–21. doi: 10.1007/s00702-012-0792-0. X-3, X-422460295
1086 Freuler A, Baranek GT, Watson LR, . Precursors and Trajectories of Sensory Features: Qualitative Analysis of Infant Home Videos. American Journal of Occupational Therapy. 2012;66(5):e81–4 1p. doi: 10.5014/ajot.2012.004465. Language: English. Entry Date: 20121121. Revision Date: 20150819. Publication Type: Journal Article. X-122917133
1087 Fritz JN, Iwata BA, Rolider NU, . Analysis of self-recording in self-management interventions for stereotypy. J Appl Behav Anal. 2012 Spring;45(1):55–68. doi: 10.1901/jaba.2012.45-55. X-122403449
1088 Froehlich AL, Anderson JS, Bigler ED, . Intact Prototype Formation but Impaired Generalization in Autism. Res Autism Spectr Disord. 2012 Spring;6(2):921–30. doi: 10.1016/j.rasd.2011.12.006. X-122291857
1089 Fung LK, Chahal L, Libove RA, . A retrospective review of the effectiveness of aripiprazole in the treatment of sensory abnormalities in autism. J Child Adolesc Psychopharmacol. 2012 Jun;22(3):245–8. doi: 10.1089/cap.2010.0103. X-3, X-422537360
1090 Gabriels RL, Agnew JA, Beresford C, . Improving psychiatric hospital care for pediatric patients with autism spectrum disorders and intellectual disabilities. Autism Res Treat. 2012;2012:685053. doi: 10.1155/2012/685053. X-122934179
1091 Gaesser GA, Angadi SS. Gluten-free diet: imprudent dietary advice for the general population? J Acad Nutr Diet. 2012 Sep;112(9):1330–3. doi: 10.1016/j.jand.2012.06.009. X-122939437
1092 Gallagher S, Whiteley J. Social support is associated with blood pressure responses in parents caring for children with developmental disabilities. Res Dev Disabil. 2012 Nov–Dec;33(6):2099–105. doi: 10.1016/j.ridd.2012.06.007. X-122771985
1093 Gantman A, Kapp SK, Orenski K, . Social skills training for young adults with high-functioning autism spectrum disorders: a randomized controlled pilot study. J Autism Dev Disord. 2012 Jun;42(6):1094–103. doi: 10.1007/s10803-011-1350-6. X-121915740
1094 Ganz JB, Heath AK, Lund EM, . Effects of peer-mediated implementation of visual scripts in middle school. Behav Modif. 2012 May;36(3):378–98. doi: 10.1177/0145445512442214. X-3, X-422582326
1095 Gardner J, Mulry CM, Chalik S. Considering college? Adolescents with autism and learning disorders participate in an on-campus service-learning program. Occup Ther Health Care. 2012 Oct;26(4):257–69. doi: 10.3109/07380577.2012.720052. X-123899200
1096 Gebregziabher M, Shotwell MS, Charles JM, . Comparison of Methods for Identifying Phenotype Subgroups Using Categorical Features Data With Application to Autism Spectrum Disorder. Comput Stat Data Anal. 2012 Jan 1;56(1):114–25. doi: 10.1016/j.csda.2011.06.014. X-121927523
1097 Geier DA, Kern JK, Geier MR. A prospective Cross-sectional Cohort Assessment of Health, Physical, and Behavioral Problems in Autism Spectrum Disorders. Maedica (Buchar). 2012 Sep;7(3):193–200. X-123400046
1098 Geiger KB, Carr JE, Leblanc LA, . Teaching receptive discriminations to children with autism: a comparison of traditional and embedded discrete trial teaching. Behav Anal Pract. 2012 Winter;5(2):49–59. X-423730466
1099 Geretsegger M, Holck U, Gold C. Randomised controlled trial of improvisational music therapy’s effectiveness for children with autism spectrum disorders (TIME-A): study protocol. BMC Pediatr. 2012;12:2. doi: 10.1186/1471-2431-12-2. X-1, X-222221670
1100 Getchell N, Miccinello D, Blom M, . Comparing Energy Expenditure in Adolescents With and Without Autism While Playing Nintendo((R)) Wii() Games. Games Health J. 2012 Feb;1(1):58–61. doi: 10.1089/g4h.2011.0019. X-126196433
1101 Geurts HM, Jansen MD. A retrospective chart study: the pathway to a diagnosis for adults referred for ASD assessment. Autism. 2012 May;16(3):299–305. doi: 10.1177/1362361311421775. X-121949003
1102 Ghanizadeh A. Hydrogen as a novel hypothesized emerging treatment for oxidative stress in autism. Eur Rev Med Pharmacol Sci. 2012 Sep;16(9):1313–4. X-1, X-223047522
1103 Ghanizadeh A. Hyperbaric oxygen therapy for treatment of children with autism: a systematic review of randomized trials. Med Gas Res. 2012;2:13. doi: 10.1186/2045-9912-2-13. X-222577817
1104 Ghanizadeh A. Atomoxetine for comorbid autism and ADHD symptoms. Brown University Child & Adolescent Psychopharmacology Update. 2012;14(6):6- 1p. Language: English. Entry Date: 20120625. Revision Date: 20150711. Publication Type: Journal Article. Journal Subset: Biomedical. X-1, X-2
1105 Ghanizadeh A, Derakhshan N. N-acetylcysteine for treatment of autism, a case report. J Res Med Sci. 2012 Oct;17(10):985–7. X-3, X-423826003
1106 Giarelli E, Ruttenberg J, Segal A. Continuing education for nurses in the clinical management of autism spectrum disorders: results of a pilot evaluation. J Contin Educ Nurs. 2012 Apr;43(4):169–76. doi: 10.3928/00220124-20111115-01. X-122106877
1107 Giles AF, St Peter CC, Pence ST, . Preference for blocking or response redirection during stereotypy treatment. Res Dev Disabil. 2012 Nov–Dec;33(6):1691–700. doi: 10.1016/j.ridd.2012.05.008. X-1, X-3, X-422695072
1108 Gleberzon BJ, Arts J, Mei A, . The use of spinal manipulative therapy for pediatric health conditions: a systematic review of the literature. J Can Chiropr Assoc. 2012 Jun;56(2):128–41. X-122675226
1109 Goldman S, Greene PE. Stereotypies in autism: a video demonstration of their clinical variability. Front Integr Neurosci. 2012;6:121. doi: 10.3389/fnint.2012.00121. X-123316144
1110 Golnik A, Maccabee-Ryaboy N, Scal P, . Shared decision making: improving care for children with autism. Intellect Dev Disabil. 2012 Aug;50(4):322–31. doi: 10.1352/1934-9556-50.4.322. X-122861133
1111 Golnik A, Scal P, Wey A, . Autism-specific primary care medical home intervention. J Autism Dev Disord. 2012 Jun;42(6):1087–93. doi: 10.1007/s10803-011-1351-5. X-121853373
1112 Gor RA, Fuhrer J, Schober JM. A retrospective observational study of enuresis, daytime voiding symptoms, and response to medical therapy in children with attention deficit hyperactivity disorder and autism spectrum disorder. J Pediatr Urol. 2012 Jun;8(3):314–7. doi: 10.1016/j.jpurol.2010.10.009. X-3, X-421131234
1113 Grabrucker AM. Environmental factors in autism. Front Psychiatry. 2012;3:118. doi: 10.3389/fpsyt.2012.00118. X-123346059
1114 Graff RB, Karsten AM. Evaluation of a self-instruction package for conducting stimulus preference assessments. J Appl Behav Anal. 2012 Spring;45(1):69–82. doi: 10.1901/jaba.2012.45-69. X-122403450
1115 Grandgeorge M, Tordjman S, Lazartigues A, . Does pet arrival trigger prosocial behaviors in individuals with autism? PLoS One. 2012;7(8):e41739. doi: 10.1371/journal.pone.0041739. X-122870246
1116 Grannan L, Rehfeldt RA. Emergent intraverbal responses via tact and match-to-sample instruction. J Appl Behav Anal. 2012 Fall;45(3):601–5. doi: 10.1901/jaba.2012.45-601. X-3, X-423060673
1117 Green D. Limitations of Meta-Analyses…Fournier, K. A., Hass, C. J., Naik, S. K., et al (2010). Motor coordination in autism spectrum disorders: A synthesis and meta-analysis. Journal of Autism and Developmental Disorders, 40, 1227–1240. Journal of Autism & Developmental Disorders. 2012;42(8):1774–5 2p. doi: 10.1007/s10803-011-1405-8. Language: English. Entry Date: 20120724. Revision Date: 20150711. Publication Type: Journal Article. X-1, X-222083783
1118 Greffou S, Bertone A, Hahler E-M, . Postural Hypo-Reactivity in Autism is Contingent on Development and Visual Environment: A Fully Immersive Virtual Reality Study. Journal of Autism & Developmental Disorders. 2012;42(6):961–70 10p. doi: 10.1007/s10803-011-1326-6. Language: English. Entry Date: 20120604. Revision Date: 20150711. Publication Type: Journal Article. X-121751061
1119 Griffith GM, Totsika V, Nash S, . ‘I just don’t fit anywhere’: support experiences and future support needs of individuals with Asperger syndrome in middle adulthood. Autism. 2012 Sep;16(5):532–46. doi: 10.1177/1362361311405223. X-121610188
1120 Grindle CF, Hastings RP, Saville M, . Outcomes of a behavioral education model for children with autism in a mainstream school setting. Behav Modif. 2012 May;36(3):298–319. doi: 10.1177/0145445512441199. X-422569577
1121 Grinker RR, Chambers N, Njongwe N, . “Communities” in community engagement: lessons learned from autism research in South Korea and South Africa. Autism Res. 2012 Jun;5(3):201–10. doi: 10.1002/aur.1229. X-122566396
1122 Gross E, El-Baz AS, Sokhadze GE, . INDUCED EEG GAMMA OSCILLATION ALIGNMENT IMPROVES DIFFERENTIATION BETWEEN AUTISM AND ADHD GROUP RESPONSES IN A FACIAL CATEGORIZATION TASK. J Neurother. 2012 Jan 1;16(2):78–91. doi: 10.1080/10874208.2012.677631. X-122754277
1123 Grossman RB, Tager-Flusberg H. “Who said that?” Matching of low- and high-intensity emotional prosody to facial expressions by adolescents with ASD. J Autism Dev Disord. 2012 Dec;42(12):2546–57. doi: 10.1007/s10803-012-1511-2. X-122450703
1124 Grynszpan O, Nadel J, Martin JC, . Self-monitoring of gaze in high functioning autism. J Autism Dev Disord. 2012 Aug;42(8):1642–50. doi: 10.1007/s10803-011-1404-9. X-122102292
1125 Gucev Z, Tasic V, Polenakovic M. Meeting Report: Rare disease in southeastern Europe, 15–17 November 2012, Skopje, Republic of Macedonia. Prilozi. 2012 Dec;33(2):279–81. X-122983106
1126 Gurkan CK, Hagerman RJ. TARGETED TREATMENTS IN AUTISM AND FRAGILE X SYNDROME. Res Autism Spectr Disord. 2012 Oct 1;6(4):1311–20. doi: 10.1016/j.rasd.2012.05.007. X-1, X-2, X-3, X-423162607
1127 Gutman SA, Raphael-Greenfield EI, Rao AK. Effect of a motor-based role-play intervention on the social behaviors of adolescents with high-functioning autism: multiple-baseline single-subject design. Am J Occup Ther. 2012 Sep–Oct;66(5):529–37. doi: 10.5014/ajot.2012.003756. X-122917119
1128 Guzinski EM, Cihon TM, Eshleman J. The effects of tact training on stereotypic vocalizations in children with autism. Anal Verbal Behav. 2012;28(1):101–10. X-1, X-3, X-422754107
1129 Hagenmuller F, Rossler W, Endrass J, . [Impaired resonance in offenders with psychopathic traits]. Neuropsychiatr. 2012;26(2):65–71. doi: 10.1007/s40211-012-0015-9. X-122836550
1130 Hahn S. Environments and autistic spectrum conditions. Nurs Times. 2012 Dec 4–10;108(49):23–5. X-1
1131 Hall HR, Graff JC. Maladaptive behaviors of children with autism: parent support, stress, and coping. Issues Compr Pediatr Nurs. 2012;35(3–4):194–214. doi: 10.3109/01460862.2012.734210. X-123140414
1132 Hall SE, Riccio CA. Complementary and alternative treatment use for autism spectrum disorders. Complement Ther Clin Pract. 2012 Aug;18(3):159–63. doi: 10.1016/j.ctcp.2012.03.004. X-122789791
1133 Halpert J. Altering the primal environment: health effects associated with assisted reproductive technologies. Environ Health Perspect. 2012 Oct;120(10):a390–5. doi: 10.1289/ehp.120-a390. X-123026346
1134 Han S, Tai C, Westenbroek RE, . Autistic-like behaviour in Scn1a+/− mice and rescue by enhanced GABA-mediated neurotransmission. Nature. 2012 Sep 20;489(7416):385–90. doi: 10.1038/nature11356. X-122914087
1135 Hanley GP. Functional assessment of problem behavior: dispelling myths, overcoming implementation obstacles, and developing new lore. Behav Anal Pract. 2012 Summer;5(1):54–72. X-123326630
1136 Hardan AY, Fung LK, Libove RA, . A randomized controlled pilot trial of oral N-acetylcysteine in children with autism. Biol Psychiatry. 2012 Jun 1;71(11):956–61. doi: 10.1016/j.biopsych.2012.01.014.22342106
1137 Harfterkamp M, van de Loo-Neus G, Minderaa RB, . A randomized double-blind study of atomoxetine versus placebo for attention-deficit/hyperactivity disorder symptoms in children with autism spectrum disorder. J Am Acad Child Adolesc Psychiatry. 2012 Jul;51(7):733–41. doi: 10.1016/j.jaac.2012.04.011.22721596
1138 Harris C, Card B. A pilot study to evaluate nutritional influences on gastrointestinal symptoms and behavior patterns in children with Autism Spectrum Disorder. Complement Ther Med. 2012 Dec;20(6):437–40. doi: 10.1016/j.ctim.2012.08.004. X-1, X-3, X-423131376
1139 Hasanzadeh E, Mohammadi MR, Ghanizadeh A, . A double-blind placebo controlled trial of Ginkgo biloba added to risperidone in patients with autistic disorders. Child Psychiatry Hum Dev. 2012 Oct;43(5):674–82. doi: 10.1007/s10578-012-0292-3.22392415
1140 Hellwig JP. Birth Trends. Nursing for Women’s Health. 2012;16(3):192–7 6p. doi: 10.1111/j.1751-486X.2012.01729.x. Language: English. Entry Date: 20120619. Revision Date: 20150711. Publication Type: Journal Article. X-1
1141 Herren J. Unbound April. Narrat Inq Bioeth. 2012 Winter;2(3):E3–5. doi: 10.1353/nib.2012.0064. X-1, X-224406894
1142 Higashida H, Yokoyama S, Huang JJ, . Social memory, amnesia, and autism: brain oxytocin secretion is regulated by NAD+ metabolites and single nucleotide polymorphisms of CD38. Neurochem Int. 2012 Nov;61(6):828–38. doi: 10.1016/j.neuint.2012.01.030. X-122366648
1143 Hill EL, Crane L, Bremner AJ. Developmental disorders and multisensory perception. Multisensory development.: Oxford University Press, New York, NY; 2012:273–300.
1144 Ho JD, Nystrom PC, Calvo DV, . Prehospital chemical restraint of a noncommunicative autistic minor by law enforcement. Prehospital Emergency Care. 2012;16(3):407–11 5p. doi: 10.3109/10903127.2011.640767. Language: English. Entry Date: 20120803. Revision Date: 20150820. Publication Type: Journal Article. X-122235798
1145 Ho JG, Caldwell RL, McDougle CJ, . The effects of aripiprazole on electrocardiography in children with pervasive developmental disorders. J Child Adolesc Psychopharmacol. 2012 Aug;22(4):277–83. doi: 10.1089/cap.2011.0129. X-1, X-322849533
1146 Hoddenbach E, Koot HM, Clifford P, . Individual differences in the efficacy of a short theory of mind intervention for children with autism spectrum disorder: a randomized controlled trial. Trials. 2012;13:206. doi: 10.1186/1745-6215-13-206. X-223140338
1147 Hoglund LT, Scott BW. Automobilization intervention and exercise for temporomandibular joint open lock. J Man Manip Ther. 2012 Nov;20(4):182–91. doi: 10.1179/2042618612y.0000000008. X-124179326
1148 Hollander E, Soorya L, Chaplin W, . A double-blind placebo-controlled trial of fluoxetine for repetitive behaviors and global severity in adult autism spectrum disorders. Am J Psychiatry. 2012 Mar;169(3):292–9. doi: 10.1176/appi.ajp.2011.10050764. X-122193531
1149 Holler K, Scalzo A. “I’ve heard some things that scare me”. Responding with empathy to parents’ fears of vaccinations. Mo Med. 2012 Jan–Feb;109(1):10–3, 6–8. X-1
1150 Honaker D, Rosello SS, Candler C. Test-retest reliability of Family L.I.F.E. (Looking Into Family Experiences): an occupation-based assessment. Am J Occup Ther. 2012 Sep–Oct;66(5):617–20. doi: 10.5014/ajot.2012.004002. X-122917128
1151 Hosenbocus S, Chahal R. A review of executive function deficits and pharmacological management in children and adolescents. J Can Acad Child Adolesc Psychiatry. 2012 Aug;21(3):223–9. X-122876270
1152 Howell DM, Wittman P, Bundy MB. Interprofessional clinical education for occupational therapy and psychology students: a social skills training program for children with autism spectrum disorders. J Interprof Care. 2012 Jan;26(1):49–55. doi: 10.3109/13561820.2011.620186. X-122233368
1153 Hugdahl K, Beyer MK, Brix M, . Autism spectrum disorder, functional MRI and MR spectroscopy: possibilities and challenges. Microb Ecol Health Dis. 2012;23 doi: 10.3402/mehd.v23i0.18960. X-1
1154 Hume K, Plavnick J, Odom S. Promoting Task Accuracy and Independence in Students with Autism Across Educational Setting Through the Use of Individual Work Systems. Journal of Autism & Developmental Disorders. 2012;42(10):2084–99 16p. doi: 10.1007/s10803-012-1457-4. Language: English. Entry Date: 20120925. Revision Date: 20150711. Publication Type: Journal Article. X-1, X-322302509
1155 Hurwitz R, Blackmore R, Hazell P, . Tricyclic antidepressants for autism spectrum disorders (ASD) in children and adolescents. Cochrane Database of Systematic Reviews. 2012(3):N.PAG-N.PAG 1p. Language: English. Entry Date: 20091023. Revision Date: 20150712. Publication Type: Journal Article. X-2
1156 Hyman SE. Revolution stalled. Sci Transl Med. 2012 Oct 10;4(155):155cm11. doi: 10.1126/scitranslmed.3003142. X-1
1157 Imperatore Blanche E, Reinoso G, Chang MC, . Proprioceptive Processing Difficulties Among Children With Autism Spectrum Disorders and Developmental Disabilities. American Journal of Occupational Therapy. 2012;66(5):621–4 4p. doi: 10.5014/ajot.2012.004234. Language: English. Entry Date: 20121121. Revision Date: 20150819. Publication Type: Journal Article. X-122917129
1158 Indah Winarni T, Chonchaiya W, Adams E, . Sertraline may improve language developmental trajectory in young children with fragile x syndrome: a retrospective chart review. Autism Res Treat. 2012;2012:104317. doi: 10.1155/2012/104317. X-122934167
1159 Ingersoll B. Brief report: effect of a focused imitation intervention on social functioning in children with autism. J Autism Dev Disord. 2012 Aug;42(8):1768–73. doi: 10.1007/s10803-011-1423-6. X-122146934
1160 Ingersoll B, Meyer K, Bonter N, . A comparison of developmental social-pragmatic and naturalistic behavioral interventions on language use and social engagement in children with autism. J Speech Lang Hear Res. 2012 Oct;55(5):1301–13. doi: 10.1044/1092-4388(2012/10-0345). X-3, X-422361104
1161 Irby MB, Kolbash S, Garner-Edwards D, . Pediatric Obesity Treatment in Children With Neurodevelopmental Disabilities: A Case Series and Review of the Literature. Infant Child Adolesc Nutr. 2012 Aug 1;4(4):215–21. doi: 10.1177/1941406412448527. X-124723990
1162 Ishitobi M, Hiratani M, Kosaka H, . Switching to aripiprazole in subjects with pervasive developmental disorders showing tolerability issues with risperidone. Prog Neuropsychopharmacol Biol Psychiatry. 2012 Apr 27;37(1):128–31. doi: 10.1016/j.pnpbp.2011.12.015. X-1, X-322245026
1163 Izawa J, Pekny SE, Marko MK, . Motor learning relies on integrated sensory inputs in ADHD, but over-selectively on proprioception in autism spectrum conditions. Autism Res. 2012 Apr;5(2):124–36. doi: 10.1002/aur.1222. X-122359275
1164 Janssen R, Maes B. Psychometric evaluation of a Dutch version of the Mini PAS-ADD for assessing psychiatric disorders in adults with different levels of intellectual disability. J Intellect Disabil Res. 2012 Mar 28 doi: 10.1111/j.1365-2788.2012.01544.x. X-1
1165 Jordan I, Robertson D, Catani M, . Aripiprazole in the treatment of challenging behaviour in adults with autism spectrum disorder. Psychopharmacology (Berl). 2012 Oct;223(3):357–60. doi: 10.1007/s00213-012-2723-z. X-122535309
1166 Joshi G, Biederman J, Wozniak J, . Response to second generation antipsychotics in youth with comorbid bipolar disorder and autism spectrum disorder. CNS Neurosci Ther. 2012 Jan;18(1):28–33. doi: 10.1111/j.1755-5949.2010.00219.x. X-1, X-321114638
1167 Juneja M, Mukherjee SB, Sharma S, . Evaluation of a parent-based behavioral intervention program for children with autism in a low-resource setting. J Pediatr Neurosci. 2012 Jan;7(1):16–8. doi: 10.4103/1817-1745.97612. X-3, X-422837770
1168 Jurgens A, Anderson A, Moore DW. Parent-implemented picture exchange communication system (PECS) training: an analysis of YouTube videos. Dev Neurorehabil. 2012;15(5):351–60. doi: 10.3109/17518423.2012.692125. X-1, X-322712574
1169 Kaale A, Smith L, Sponheim E. A randomized controlled trial of preschool-based joint attention intervention for children with autism. J Child Psychol Psychiatry. 2012 Jan;53(1):97–105. doi: 10.1111/j.1469-7610.2011.02450.x. X-121883204
1170 Kadar M, McDonald R, Lentin P. Evidence-based practice in occupational therapy services for children with autism spectrum disorders in Victoria, Australia. Aust Occup Ther J. 2012 Aug;59(4):284–93. doi: 10.1111/j.1440-1630.2012.01015.x. X-122934901
1171 Kalas A. Joint attention responses of children with autism spectrum disorder to simple versus complex music. J Music Ther. 2012 Winter;49(4):430–52. X-323705346
1172 Kalb LG, Stuart EA, Freedman B, . Psychiatric-related emergency department visits among children with an autism spectrum disorder. Pediatr Emerg Care. 2012 Dec;28(12):1269–76. doi: 10.1097/PEC.0b013e3182767d96. X-123187983
1173 Kalnak N, Peyrard-Janvid M, Sahlen B, . Family history interview of a broad phenotype in specific language impairment and matched controls. Genes Brain Behav. 2012 Nov;11(8):921–7. doi: 10.1111/j.1601-183X.2012.00841.x. X-122928858
1174 Kaluzna-Czaplinska J, Blaszczyk S. The level of arabinitol in autistic children after probiotic therapy. Nutrition. 2012 Feb;28(2):124–6. doi: 10.1016/j.nut.2011.08.002. X-322079796
1175 Kamp-Becker I, Baumann K, Sprenger L, . [The concept of <<multiple complex developmental disorder>> - a disorder of social interaction, paranoid thinking and social anxiety in a 17-year-old boy]. Z Kinder Jugendpsychiatr Psychother. 2012 Sep;40(5):341–9. doi: 10.1024/1422-4917/a000191. X-122869228
1176 Kanda Y, Kumagami H, Hara M, . What factors are associated with good performance in children with cochlear implants? From the outcome of various language development tests, research on sensory and communicative disorders project in Japan: nagasaki experience. Clin Exp Otorhinolaryngol. 2012 Apr;5(Suppl 1):S59–64. doi: 10.3342/ceo.2012.5.S1.S59. X-122701149
1177 Kaplan G, McCracken JT. Psychopharmacology of autism spectrum disorders. Pediatric Clinics of North America. 2012;59(1):175–87 13p. Language: English. Entry Date: 20120413. Revision Date: 20150712. Publication Type: Journal Article. X-1, X-222284801
1178 Kasari C, Gulsrud A, Freeman S, . Longitudinal follow-up of children with autism receiving targeted interventions on joint attention and play. J Am Acad Child Adolesc Psychiatry. 2012 May;51(5):487–95. doi: 10.1016/j.jaac.2012.02.019. X-1, X-322525955
1179 Kasari C, Rotheram-Fuller E, Locke J, . Making the connection: randomized controlled trial of social skills at school for children with autism spectrum disorders. J Child Psychol Psychiatry. 2012 Apr;53(4):431–9. doi: 10.1111/j.1469-7610.2011.02493.x. X-122118062
1180 Katsnelson A. The autism pill. Sci Am. 2012 Nov;307(5):16. X-1, X-2
1181 Khanna R, Jariwala K. Awareness and knowledge of autism among pharmacists. Res Social Adm Pharm. 2012 Sep–Oct;8(5):464–71. doi: 10.1016/j.sapharm.2011.11.002. X-122222344
1182 Khanna R, Madhavan SS, Smith MJ, . Psychometric properties of the Caregiver Strain Questionnaire (CGSQ) among caregivers of children with autism. Autism. 2012 Mar;16(2):179–99. doi: 10.1177/1362361311406143. X-121715548
1183 Kheir NM, Ghoneim OM, Sandridge AL, . Concerns and considerations among caregivers of a child with autism in Qatar. BMC Res Notes. 2012;5:290. doi: 10.1186/1756-0500-5-290. X-122695064
1184 Kinnealey M, Pfeiffer B, Miller J, . Effect of classroom modification on attention and engagement of students with autism or dyspraxia. Am J Occup Ther. 2012 Sep–Oct;66(5):511–9. doi: 10.5014/ajot.2012.004010. X-122917117
1185 Klintwall L, Gillberg C, Bolte S, . The efficacy of intensive behavioral intervention for children with autism: a matter of allegiance? J Autism Dev Disord. 2012 Jan;42(1):139–40. doi: 10.1007/s10803-011-1223-z. X-1, X-321424234
1186 Knoth IS, Lippe S. Event-related potential alterations in fragile X syndrome. Front Hum Neurosci. 2012;6:264. doi: 10.3389/fnhum.2012.00264. X-123015788
1187 Kobayashi T, Inagaki M, Kaga M. Professional Caregiver’s View on Mental Health in Parents of Children with Developmental Disabilities: A Nationwide Study of Institutions and Consultation Centers in Japan. ISRN Pediatr. 2012;2012:121898. doi: 10.5402/2012/121898. X-122389791
1188 Kodak T, Fuchtman R, Paden A. A comparison of intraverbal training procedures for children with autism. J Appl Behav Anal. 2012 Spring;45(1):155–60. doi: 10.1901/jaba.2012.45-155. X-1, X-3, X-422403459
1189 Kodak T, Paden A, Dickes N. Training and Generalization of Peer-Directed Mands With Non-vocal Children With Autism. Anal Verbal Behav. 2012;28(1):119–24. X-1, X-3, X-422754109
1190 Koegel LK, Kuriakose S, Singh AK, . Improving generalization of peer socialization gains in inclusive school settings using initiations training. Behav Modif. 2012 May;36(3):361–77. doi: 10.1177/0145445512445609. X-3, X-422645399
1191 Koegel LK, Vernon T, Koegel RL, . Improving Social Engagement and Initiations between Children with Autism Spectrum Disorder and Their Peers in Inclusive Settings. J Posit Behav Interv. 2012 Oct;14(4):220–7. doi: 10.1177/1098300712437042. X-1, X-425328380
1192 Koegel R, Fredeen R, Kim S, . Using Perseverative Interests to Improve Interactions Between Adolescents with Autism and their Typical Peers in School Settings. J Posit Behav Interv. 2012 Jul 1;14(3):133–41. doi: 10.1177/1098300712437043. X-124163577
1193 Koegel RL, Bharoocha AA, Ribnick CB, . Using individualized reinforcers and hierarchical exposure to increase food flexibility in children with autism spectrum disorders. J Autism Dev Disord. 2012 Aug;42(8):1574–81. doi: 10.1007/s10803-011-1392-9. X-1, X-3, X-422042309
1194 Koenig KP, Buckley-Reen A, Garg S. Efficacy of the Get Ready to Learn yoga program among children with autism spectrum disorders: a pretest-posttest control group design. Am J Occup Ther. 2012 Sep–Oct;66(5):538–46. doi: 10.5014/ajot.2012.004390. X-1, X-322917120
1195 Kohannim O, Hibar DP, Stein JL, . Discovery and Replication of Gene Influences on Brain Structure Using LASSO Regression. Front Neurosci. 2012;6:115. doi: 10.3389/fnins.2012.00115. X-122888310
1196 Kohls G, Chevallier C, Troiani V, . Social ‘wanting’ dysfunction in autism: neurobiological underpinnings and treatment implications. J Neurodev Disord. 2012;4(1):10. doi: 10.1186/1866-1955-4-10. X-122958468
1197 Kotagal S. Treatment of dyssomnias and parasomnias in childhood. Curr Treat Options Neurol. 2012 Dec;14(6):630–49. doi: 10.1007/s11940-012-0199-0. X-123011807
1198 Kramer JM, Coster WJ, Kao YC, . A new approach to the measurement of adaptive behavior: development of the PEDI-CAT for children and youth with autism spectrum disorders. Phys Occup Ther Pediatr. 2012 Feb;32(1):34–47. doi: 10.3109/01942638.2011.606260. X-121846290
1199 Krieger B, Kinebanian A, Prodinger B, . Becoming a member of the work force: perceptions of adults with Asperger Syndrome. Work. 2012;43(2):141–57. doi: 10.3233/wor-2012-1392. X-122927626
1200 Lajonchere C, Jones N, Coury DL, . Leadership in health care, research, and quality improvement for children and adolescents with autism spectrum disorders: Autism Treatment Network and Autism Intervention Research Network on Physical Health. Pediatrics. 2012 Nov;130(Suppl 2):S62–8. doi: 10.1542/peds.2012-0900C. X-123118255
1201 Landa RJ, Kalb LG. Long-term outcomes of toddlers with autism spectrum disorders exposed to short-term intervention. Pediatrics. 2012 Nov;130(Suppl 2):S186–90. doi: 10.1542/peds.2012-0900Q. X-1, X-323118250
1202 Lane A, Harpster K, Heathcock J. Motor characteristics of young children referred for possible autism spectrum disorder. Pediatric Physical Therapy. 2012 2012 Spring;24(1):21–9 9p. Language: English. Entry Date: 20120406. Revision Date: 20150820. Publication Type: Journal Article. X-122207461
1203 Lane SJ, Reynolds S, Dumenci L. Sensory overresponsivity and anxiety in typically developing children and children with autism and attention deficit hyperactivity disorder: cause or coexistence? Am J Occup Ther. 2012 Sep–Oct;66(5):595–603. doi: 10.5014/ajot.2012.004523. X-122917126
1204 Lang R, O’Reilly M, Healy O, . Sensory integration therapy for autism spectrum disorders: A systematic review. Research in Autism Spectrum Disorders. 2012 2015-02-24;6(3):1004–18. doi: http://dx.doi.org/10.1016/j.rasd.2012.01.006; 2012-13564-007. X-1, X-2
1205 Laugeson EA, Frankel F, Gantman A, . Evidence-based social skills training for adolescents with autism spectrum disorders: the UCLA PEERS program. J Autism Dev Disord. 2012 Jun;42(6):1025–36. doi: 10.1007/s10803-011-1339-1. X-121858588
1206 Lawton K, Kasari C. Teacher-implemented joint attention intervention: pilot randomized controlled study for preschoolers with autism. J Consult Clin Psychol. 2012 Aug;80(4):687–93. doi: 10.1037/a0028506. X-122582764
1207 Leaf JB, Oppenheim-Leaf ML, Call NA, . Comparing the teaching interaction procedure to social stories for people with autism. J Appl Behav Anal. 2012 Summer;45(2):281–98. doi: 10.1901/jaba.2012.45-281. X-3, X-422844137
1208 Lemonda BC, Holtzer R, Goldman S. Relationship between executive functions and motor stereotypies in children with Autistic Disorder. Res Autism Spectr Disord. 2012 Jul 1;6(3):1099–106. doi: 10.1016/j.rasd.2012.03.001. X-123637708
1209 Lemonnier E, Degrez C, Phelep M, . A randomised controlled trial of bumetanide in the treatment of autism in children. Transl Psychiatry. 2012;2:e202. doi: 10.1038/tp.2012.124.23233021
1210 Lerna A, Esposito D, Conson M, . Social-communicative effects of the Picture Exchange Communication System (PECS) in autism spectrum disorders. Int J Lang Commun Disord. 2012 Sep–Oct;47(5):609–17. doi: 10.1111/j.1460-6984.2012.00172.x. X-422938071
1211 Leupen A. Proteus for autistic children with temper tantrums. Homoeopathic Links. 2012;25(2):120- 1p. Language: English. Entry Date: 20120907. Revision Date: 20150711. Publication Type: Journal Article. X-1, X-2
1212 Levine TP, Sheinkopf SJ, Pescosolido M, . Physiologic Arousal to Social Stress in Children with Autism Spectrum Disorders: A Pilot Study. Res Autism Spectr Disord. 2012 Winter;6(1):177–83. doi: 10.1016/j.rasd.2011.04.003. X-122081773
1213 Levy-Osborne S. Thinking about the past hoping for the future. Narrat Inq Bioeth. 2012 Winter;2(3):E5–7. doi: 10.1353/nib.2012.0067. X-124406895
1214 Li K-H, Lou S-J, Tsai H-Y, . The effects of applying game-based learning to Webcam motion sensor games for autistic students’ sensory integration training. TOJET: The Turkish Online Journal of Educational Technology. 2012 2015-02-24;11(4):451–9. doi: 10.6223/qcpe.2601.201203.2005; 2013-28852-044. X-3, X-4
1215 Lian WB, Ho SK, Choo SH, . Children with developmental and behavioural concerns in Singapore. Singapore Med J. 2012 Jul;53(7):439–45. X-122815011
1216 Lickel A, MacLean WE, Jr., Blakeley-Smith A, . Assessment of the prerequisite skills for cognitive behavioral therapy in children with and without autism spectrum disorders. J Autism Dev Disord. 2012 Jun;42(6):992–1000. doi: 10.1007/s10803-011-1330-x. X-1, X-321818677
1217 Lin A, Rangel A, Adolphs R. Impaired learning of social compared to monetary rewards in autism. Front Neurosci. 2012;6:143. doi: 10.3389/fnins.2012.00143. X-123060743
1218 Lin A, Tsai K, Rangel A, . Reduced social preferences in autism: evidence from charitable donations. J Neurodev Disord. 2012;4(1):8. doi: 10.1186/1866-1955-4-8. X-122958506
1219 Lin LY, Yu SN, Yu YT. A study of activities of daily living and employment in adults with autism spectrum disorders in Taiwan. Int J Rehabil Res. 2012 Jun;35(2):109–15. doi: 10.1097/MRR.0b013e32835108b1. X-122334003
1220 Lindberg S, von Post I, Eriksson K. The experiences of parents of children with severe autism in connection with their children’s anaesthetics, in the presence and absence of the perioperative dialogue: a hermeneutic study. Scandinavian Journal of Caring Sciences. 2012;26(4):627–34 8p. doi: 10.1111/j.1471-6712.2012.00971.x. Language: English. Entry Date: 20121109. Revision Date: 20150819. Publication Type: Journal Article. X-122324909
1221 Ling CY, Mak WW. Coping with challenging behaviours of children with autism: effectiveness of brief training workshop for frontline staff in special education settings. J Intellect Disabil Res. 2012 Mar;56(3):258–69. doi: 10.1111/j.1365-2788.2011.01469.x. X-121955252
1222 Lit L, Sharp FR, Bertoglio K, . Gene expression in blood is associated with risperidone response in children with autism spectrum disorders. Pharmacogenomics J. 2012 Oct;12(5):368–71. doi: 10.1038/tpj.2011.23. X-321647175
1223 Litresh W, Lei G, Shirley A, . Gross motor skills of children with autism. American Journal of Recreation Therapy. 2012;11(3):39–47 9p. Language: English. Entry Date: 20130322. Revision Date: 20150818. Publication Type: Journal Article. X-1
1224 Lo SY. Diagnosis, treatment and prevention of autism via meridian theory. Am J Chin Med. 2012;40(1):39–56. doi: 10.1142/s0192415x12500048. X-1, X-322298447
1225 Lofthouse N, Hendren R, Hurt E, . A review of complementary and alternative treatments for autism spectrum disorders. Autism Res Treat. 2012;2012:870391. doi: 10.1155/2012/870391. X-1, X-223243505
1226 Logan SL, Nicholas JS, Carpenter LA, . High prescription drug use and associated costs among Medicaid-eligible children with autism spectrum disorders identified by a population-based surveillance network. Ann Epidemiol. 2012 Jan;22(1):1–8. doi: 10.1016/j.annepidem.2011.10.007. X-122153288
1227 Lokhandwala T, Khanna R, West-Strum D. Hospitalization burden among individuals with autism. J Autism Dev Disord. 2012 Jan;42(1):95–104. doi: 10.1007/s10803-011-1217-x. X-121404084
1228 Lombardo MV, Chakrabarti B, Lai MC, . Self-referential and social cognition in a case of autism and agenesis of the corpus callosum. Mol Autism. 2012;3(1):14. doi: 10.1186/2040-2392-3-14. X-123171505
1229 Lopatina O, Inzhutova A, Salmina AB, . The roles of oxytocin and CD38 in social or parental behaviors. Front Neurosci. 2012;6:182. doi: 10.3389/fnins.2012.00182. X-123335873
1230 Lopez M, Bellando J. An informal survey on family/caregiver wishes for individuals with autism in Arkansas. J Ark Med Soc. 2012 Dec;109(7):137–9. X-123304848
1231 Lopez M, Schulz EG, Baroud T, . The Arkansas Autism Developmental Disabilities Monitoring (AR ADDM) project: statewide autism surveillance in a rural state. J Ark Med Soc. 2012 Mar;108(10):220, 2–4. X-1
1232 Lorange M, Kristmundsdottir K, Skarphedinsson G, . [Relationship between pre-adoptive risk factors and psychopathological difficulties of internationally adopted children in Iceland]. Laeknabladid. 2012 Jan;98(1):19–23. X-122253083
1233 Lough CL, Rice MS, Lough LG. Choice as a strategy to enhance engagement in a colouring task in children with autism spectrum disorders. Occup Ther Int. 2012 Dec;19(4):204–11. doi: 10.1002/oti.1337. X-1, X-323019122
1234 Love JJ, Miguel CF, Fernand JK, . The effects of matched stimulation and response interruption and redirection on vocal stereotypy. J Appl Behav Anal. 2012 Fall;45(3):549–64. doi: 10.1901/jaba.2012.45-549. X-3, X-423060668
1235 Lovell B, Moss M, Wetherell M. The psychosocial, endocrine and immune consequences of caring for a child with autism or ADHD. Psychoneuroendocrinology. 2012 Apr;37(4):534–42. doi: 10.1016/j.psyneuen.2011.08.003. X-121889267
1236 Lundervold AJ, Stickert M, Hysing M, . Attention Deficits in Children With Combined Autism and ADHD: A CPT Study. J Atten Disord. 2012 Aug 31 doi: 10.1177/1087054712453168. X-1
1237 Lutz HR, Patterson BJ, Klein J. Coping with autism: a journey toward adaptation. J Pediatr Nurs. 2012 Jun;27(3):206–13. doi: 10.1016/j.pedn.2011.03.013. X-122525808
1238 Lyall K, Pauls DL, Spiegelman D, . Fertility therapies, infertility and autism spectrum disorders in the Nurses’ Health Study II. Paediatr Perinat Epidemiol. 2012 Jul;26(4):361–72. doi: 10.1111/j.1365-3016.2012.01294.x. X-122686388
1239 Magana S, Parish SL, Rose RA, . Racial and ethnic disparities in quality of health care among children with autism and other developmental disabilities. Intellect Dev Disabil. 2012 Aug;50(4):287–99. doi: 10.1352/1934-9556-50.4.287. X-122861130
1240 Mahajan R, Pilar Bernal M, Panzer R, . Clinical Practice Pathways for Evaluation and Medication Choice for Attention-Deficit/Hyperactivity Disorder Symptoms in Autism Spectrum Disorders. Pediatrics. 2012;130:S125–38 1p. doi: 10.1542/peds.2012-0900J. Language: English. Entry Date: 20121106. Revision Date: 20150712. Publication Type: Journal Article. X-223118243
1241 Main PA, Angley MT, O’Doherty CE, . The potential role of the antioxidant and detoxification properties of glutathione in autism spectrum disorders: a systematic review and meta-analysis. Nutr Metab (Lond). 2012;9:35. doi: 10.1186/1743-7075-9-35. X-222524510
1242 Mak-Fan K, Taylor M, Roberts W, . Measures of Cortical Grey Matter Structure and Development in Children with Autism Spectrum Disorder. Journal of Autism & Developmental Disorders. 2012;42(3):419–27 9p. doi: 10.1007/s10803-011-1261-6. Language: English. Entry Date: 20120509. Revision Date: 20150711. Publication Type: Journal Article. X-121556969
1243 Malow B, Adkins KW, McGrew SG, . Melatonin for sleep in children with autism: a controlled trial examining dose, tolerability, and outcomes. J Autism Dev Disord. 2012 Aug;42(8):1729–37; author reply 38. doi: 10.1007/s10803-011-1418-3. X-322160300
1244 Mandell DS. Understanding and addressing the impact of autism on the family. LDI Issue Brief. 2012 Apr–May;17(7):1–4. X-1
1245 Mandell DS, Xie M, Morales KH, . The interplay of outpatient services and psychiatric hospitalization among Medicaid-enrolled children with autism spectrum disorders. Arch Pediatr Adolesc Med. 2012 Jan;166(1):68–73. doi: 10.1001/archpediatrics.2011.714. X-122213753
1246 Mangum A, Roane H, Fredrick L, . The Role of Context in the Evaluation of Reinforcer Efficacy: Implications for the Preference Assessment Outcomes. Res Autism Spectr Disord. 2012 Jan;6(1):158–67. doi: 10.1016/j.rasd.2011.04.001. X-122125577
1247 Manohara D. Primary care management of tuberous sclerosis complex in children. Journal of the American Academy of Nurse Practitioners. 2012;24(7):391–9 9p. doi: 10.1111/j.1745-7599.2012.00734.x. Language: English. Entry Date: 20120716. Revision Date: 20150819. Publication Type: Journal Article. X-122735062
1248 Marchese NV, Carr JE, LeBlanc LA, . The effects of the question “What is this?” on tact-training outcomes of children with autism. J Appl Behav Anal. 2012 Fall;45(3):539–47. doi: 10.1901/jaba.2012.45-539. X-1, X-3, X-423060667
1249 Marion C, Martin GL, Yu CT, . Teaching children with autism spectrum disorder to mand for information using “which?”. J Appl Behav Anal. 2012 Winter;45(4):865–70. doi: 10.1901/jaba.2012.45-865. X-3, X-423322944
1250 Markoulakis R, Scharoun S, Bryden P, . An Examination of Handedness and Footedness in Children with High Functioning Autism and Asperger Syndrome. Journal of Autism & Developmental Disorders. 2012;42(10):2192–201 10p. doi: 10.1007/s10803-012-1469-0. Language: English. Entry Date: 20120925. Revision Date: 20150711. Publication Type: Journal Article. X-122350451
1251 Martin-Du Pan RC. [Oxytocin: the hormone of love, trust and social bond. Clinical use in autism and social phobia]. Rev Med Suisse. 2012 Mar 21;8(333):627–30. X-1, X-222506444
1252 Mashal N, Kasirer A. Principal component analysis study of visual and verbal metaphoric comprehension in children with autism and learning disabilities. Res Dev Disabil. 2012 Jan–Feb;33(1):274–82. doi: 10.1016/j.ridd.2011.09.010. X-122001558
1253 Mason RA, Rispoli M, Ganz JB, . Effects of video modeling on communicative social skills of college students with Asperger syndrome. Dev Neurorehabil. 2012;15(6):425–34. doi: 10.3109/17518423.2012.704530. X-123030681
1254 Masterson M. Autism Spectrum Disorder Update. Kansas Nurse. 2012;87(3):14–6 3p. Language: English. Entry Date: 20120615. Revision Date: 20151015. Publication Type: Journal Article. X-1, X-2
1255 Matone M, Localio R, Huang YS, . The relationship between mental health diagnosis and treatment with second-generation antipsychotics over time: a national study of U.S. Medicaid-enrolled children. Health Serv Res. 2012 Oct;47(5):1836–60. doi: 10.1111/j.1475-6773.2012.01461.x. X-122946905
1256 Matsuzaki J, Kagitani-Shimono K, Goto T, . Differential responses of primary auditory cortex in autistic spectrum disorder with auditory hypersensitivity. Neuroreport. 2012 Jan 25;23(2):113–8. doi: 10.1097/WNR.0b013e32834ebf44. X-122146579
1257 Mauron A. [Autism, stem cells, and magical powder]. Rev Med Suisse. 2012 Sep 19;8(354):1795. X-1, X-223097920
1258 May T, Cornish K, Rinehart NJ. Gender Profiles of Behavioral Attention in Children With Autism Spectrum Disorder. J Atten Disord. 2012 Aug 21 doi: 10.1177/1087054712455502. X-1
1259 Mayor S. Advertising watchdog orders website to remove claims linking MMR vaccine with autism. Bmj. 2012;345:e5420. doi: 10.1136/bmj.e5420. X-122879643
1260 Mazefsky CA, Pelphrey KA, Dahl RE. The Need for a Broader Approach to Emotion Regulation Research in Autism. Child Dev Perspect. 2012 Mar 1;6(1):92–7. doi: 10.1111/j.1750-8606.2011.00229.x. X-122639681
1261 McBride SM, Holloway SL, Jongens TA. Using as a tool to identify Pharmacological Therapies for Fragile X Syndrome. Drug Discov Today Technol. 2012 Sep 24;10(1):e129–e36. doi: 10.1016/j.ddtec.2012.09.005. X-123730322
1262 McBride SM, Holloway SL, Jongens TA. Using Drosophila as a tool to identify Pharmacological Therapies for Fragile X Syndrome. Drug Discov Today Technol. 2012 Sep 24;10(1):e129–e36. doi: 10.1016/j.ddtec.2012.09.005. X-123730322
1263 McClean B, Grey I. An evaluation of an intervention sequence outline in positive behaviour support for people with autism and severe escape-motivated challenging behaviour. J Intellect Dev Disabil. 2012 Sep;37(3):209–20. doi: 10.3109/13668250.2012.704982. X-3, X-422873574
1264 McDonald D. Much more to come! Narrat Inq Bioeth. 2012 Winter;2(3):167–70. doi: 10.1353/nib.2012.0065. X-124406881
1265 McDuffie AS, Lieberman RG, Yoder PJ. Object interest in autism spectrum disorder: a treatment comparison. Autism. 2012 Jul;16(4):398–405. doi: 10.1177/1362361309360983. X-122133872
1266 McFadden KL, Hepburn S, Winterrowd E, . Abnormalities in gamma-band responses to language stimuli in first-degree relatives of children with autism spectrum disorder: an MEG study. BMC Psychiatry. 2012;12:213. doi: 10.1186/1471-244x-12-213. X-123194079
1267 McGeown HR, Johnstone EC, McKirdy J, . Determinants of adult functional outcome in adolescents receiving special educational assistance. J Intellect Disabil Res. 2012 Feb 28 doi: 10.1111/j.1365-2788.2011.01533.x. X-1
1268 McGuinty E, Armstrong D, Nelson J, . Externalizing metaphors: anxiety and high-functioning autism. J Child Adolesc Psychiatr Nurs. 2012 Feb;25(1):9–16. doi: 10.1111/j.1744-6171.2011.00305.x. X-122299802
1269 McPartland JC, Crowley MJ, Perszyk DR, . Preserved reward outcome processing in ASD as revealed by event-related potentials. J Neurodev Disord. 2012;4(1):16. doi: 10.1186/1866-1955-4-16. X-122958616
1270 Mechling L, Ayres K. A Comparative Study: Completion of Fine Motor Office Related Tasks by High School Students with Autism Using Video Models on Large and Small Screen Sizes. Journal of Autism & Developmental Disorders. 2012;42(11):2364–73 10p. doi: 10.1007/s10803-012-1484-1. Language: English. Entry Date: 20121019. Revision Date: 20150711. Publication Type: Journal Article. X-122354709
1271 Megargel E, Broder-Fingert S. Autism and hospitals: a difficult match. Acad Pediatr. 2012 Nov–Dec;12(6):469–70. doi: 10.1016/j.acap.2012.10.002. X-123159035
1272 Meier AE, Fryling MJ, Wallace MD. Using high-probability foods to increase the acceptance of low-probability foods. J Appl Behav Anal. 2012 Spring;45(1):149–53. doi: 10.1901/jaba.2012.45-149. X-1, X-322403458
1273 Memari AH, Ziaee V, Beygi S, . Overuse of psychotropic medications among children and adolescents with autism spectrum disorders: perspective from a developing country. Res Dev Disabil. 2012 Mar–Apr;33(2):563–9. doi: 10.1016/j.ridd.2011.10.001. X-122119705
1274 Midorikawa A, Kawamura M. The Relationship between Subclinical Asperger’s Syndrome and Frontotemporal Lobar Degeneration. Dement Geriatr Cogn Dis Extra. 2012 Jan;2:180–6. doi: 10.1159/000338174. X-122719743
1275 Midtvedt T. The gut: a triggering place for autism - possibilities and challenges. Microb Ecol Health Dis. 2012;23 doi: 10.3402/mehd.v23i0.18982. X-1
1276 Mieres AC, Kirby RS, Armstrong KH, . Autism spectrum disorder: an emerging opportunity for physical therapy. Pediatric Physical Therapy. 2012 2012 Spring;24(1):31–7 7p. Language: English. Entry Date: 20120406. Revision Date: 20150820. Publication Type: Journal Article. Journal Subset: Allied Health. X-122207463
1277 Miliotis A, Sidener TM, Reeve KF, . An evaluation of the number of presentations of target sounds during stimulus-stimulus pairing trials. J Appl Behav Anal. 2012 Winter;45(4):809–13. doi: 10.9101/jaba.2012.45-809. X-123322934
1278 Miller E. Focusing on prevention. Imprint. 2012 Nov–Dec;59(5):12. X-1
1279 Ming X, Chen X, Wang XT, . Acupuncture for treatment of autism spectrum disorders. Evid Based Complement Alternat Med. 2012;2012:679845. doi: 10.1155/2012/679845. X-122203876
1280 Minne EP, Semrud-Clikeman M. A social competence intervention for young children with high functioning autism and Asperger syndrome: a pilot study. Autism. 2012 Nov;16(6):586–602. doi: 10.1177/1362361311423384. X-3, X-422087045
1281 Miyaoka T, Wake R, Furuya M, . Yokukansan (TJ-54) for treatment of pervasive developmental disorder not otherwise specified and Asperger’s disorder: a 12-week prospective, open-label study. BMC Psychiatry. 2012;12:215. doi: 10.1186/1471-244x-12-215. X-1, X-323194148
1282 Mohammadi MR, Zarafshan H, Ghasempour S. Broader Autism Phenotype in Iranian Parents of Children with Autism Spectrum Disorders vs. Normal Children. Iran J Psychiatry. 2012 Fall;7(4):157–63. X-123408558
1283 Mohinderpal Chadha G, Kakodkar P, Chaugule V, . Dental survey of institutionalized children with autistic disorder. Int J Clin Pediatr Dent. 2012 Jan;5(1):29–32. doi: 10.5005/jp-journals-10005-1130. X-125206131
1284 Moilanen I, Mattila ML, Loukusa S, . [Autism spectrum disorders in children and adolescents]. Duodecim. 2012;128(14):1453–62. X-122937604
1285 Momeni N, Brudin L, Behnia F, . High complement factor I activity in the plasma of children with autism spectrum disorders. Autism Res Treat. 2012;2012:868576. doi: 10.1155/2012/868576. X-122928102
1286 Monahan M, Classen S, Helsel P. Pre-driving skills of a teen with attention deficit hyperactivity and autism spectrum disorder. Developmental Disabilities Special Interest Section Quarterly. 2012;35(4):1–4 p. Language: English. Entry Date: 20130104. Revision Date: 20150820. Publication Type: Journal Article. X-1
1287 Motoyama K, Matsuzaka T, Nagaoka T, . [The effect of parent training program on children with attention deficit/hyperactivity disorders and/or pervasive developmental disorders]. No To Hattatsu. 2012 Jul;44(4):289–94. X-3, X-422844759
1288 Mulligan S, White BP. Sensory and motor behaviors of infant siblings of children with and without autism. American Journal of Occupational Therapy. 2012 2015-02-24;66(5):556–66. doi: http://dx.doi.org/10.5014/ajot.2012.004077; 2012-25996-006. X-122917122
1289 Murphy D, Spooren W. EU-AIMS: a boost to autism research. Nat Rev Drug Discov. 2012 Nov;11(11):815–6. doi: 10.1038/nrd3881. X-123123927
1290 Nau JY. [To dare trying a diuretic in autism treatment]. Rev Med Suisse. 2012 Dec 19;8(367):2458–9. X-1
1291 Nau JY. [Autism: who has a say in treatment?]. Rev Med Suisse. 2012 Mar 21;8(333):658–9. X-1, X-2
1292 Nayate A, Tonge B, Bradshaw J, . Differentiation of High-Functioning Autism and Asperger’s Disorder Based on Neuromotor Behaviour. Journal of Autism & Developmental Disorders. 2012;42(5):707–17 11p. doi: 10.1007/s10803-011-1299-5. Language: English. Entry Date: 20120509. Revision Date: 20150711. Publication Type: Journal Article. X-121660499
1293 Neely J, Amatea ES, Echevarria-Doan S, . Working with families living with autism: potential contributions of marriage and family therapists. J Marital Fam Ther. 2012 Jun;38(Suppl 1):211–26. doi: 10.1111/j.1752-0606.2011.00265.x. X-122765335
1294 Nicholson MS, Leask J. Lessons from an online debate about measles-mumps-rubella (MMR) immunization. Vaccine. 2012 May 28;30(25):3806–12. doi: 10.1016/j.vaccine.2011.10.072. X-122063388
1295 Nicolaidis C. What can physicians learn from the neurodiversity movement? Virtual Mentor. 2012 Jun;14(6):503–10. doi: 10.1001/virtualmentor.2012.14.6.oped1-1206. X-123351267
1296 Nikki R, Martin B, Gus O, . Endolymphatic sac enlargement in a girl with a novel mutation for distal renal tubular acidosis and severe deafness. Case Rep Pediatr. 2012;2012:605053. doi: 10.1155/2012/605053. X-122966473
1297 Novarino G, El-Fishawy P, Kayserili H, . Mutations in BCKD-kinase lead to a potentially treatable form of autism with epilepsy. Science. 2012 Oct 19;338(6105):394–7. doi: 10.1126/science.1224631. X-122956686
1298 Oberman L, Eldaief M, Fecteau S, . Abnormal modulation of corticospinal excitability in adults with Asperger’s syndrome. Eur J Neurosci. 2012 Sep;36(6):2782–8. doi: 10.1111/j.1460-9568.2012.08172.x. X-122738084
1299 O’Connor K. Auditory processing in autism spectrum disorder: a review. Neurosci Biobehav Rev. 2012 Feb;36(2):836–54. doi: 10.1016/j.neubiorev.2011.11.008. X-122155284
1300 O’Donnell S, Deitz J, Kartin D, . Sensory processing, problem behavior, adaptive behavior, and cognition in preschool children with autism spectrum disorders. American Journal of Occupational Therapy. 2012 2015-12-09;66(5):586–94. doi: http://dx.doi.org/10.5014/ajot.2012.004168; 2012-25996-009. X-122917125
1301 Olfson M, Blanco C, Liu SM. Study examines office-based antipsychotic prescribing in youth. Brown University Child & Adolescent Psychopharmacology Update. 2012;14(10):3–4 2p. doi: 10.1001/archgenpsychiatry.2012.647. Language: English. Entry Date: 20121002. Revision Date: 20150711. Publication Type: Journal Article. Journal Subset: Biomedical. X-1
1302 Oner P, Oner O, Cop E, . [Reliability and Validity of the Turkish Version of the Social Communication Scale.]. Klinik Psikofarmakol Bulteni. 2012 Jan;22(1):43–50. doi: 10.5455/bcp.20111212091514. X-125580078
1303 Onore C, Van de Water J, Ashwood P. Decreased levels of EGF in plasma of children with autism spectrum disorder. Autism Res Treat. 2012;2012:205362. doi: 10.1155/2012/205362. X-122937258
1304 O’Reilly M, Aguilar J, Fragale C, . Effects of a motivating operation manipulation on the maintenance of mands. J Appl Behav Anal. 2012 Summer;45(2):443–7. doi: 10.1901/jaba.2012.45-443. X-1, X-3, X-422844154
1305 O’Reilly M, Cook L, Karim K. Complementary or controversial care? The opinions of professionals on complementary and alternative interventions for Autistic Spectrum Disorder. Clin Child Psychol Psychiatry. 2012 Oct;17(4):602–15. doi: 10.1177/1359104511435340. X-122371629
1306 O’Reilly M, Fragale C, Gainey S, . Examination of an antecedent communication intervention to reduce tangibly maintained challenging behavior: a controlled analog analysis. Res Dev Disabil. 2012 Sep–Oct;33(5):1462–8. doi: 10.1016/j.ridd.2012.03.017. X-3, X-422543058
1307 Orekhova EV, Tsetlin MM, Butorina AV, . Auditory cortex responses to clicks and sensory modulation difficulties in children with autism spectrum disorders (ASD). PLoS One. 2012;7(6):e39906. doi: 10.1371/journal.pone.0039906. X-122768163
1308 Orellana LM, Silvestre FJ, Martinez-Sanchis S, . Oral manifestations in a group of adults with autism spectrum disorder. Med Oral Patol Oral Cir Bucal. 2012 May;17(3):e415–9. X-122143726
1309 Osteen M. Leaving limbo. Narrat Inq Bioeth. 2012 Winter;2(3):170–3. doi: 10.1353/nib.2012.0068. X-124406882
1310 Ozsivadjian A, Knott F, Magiati I. Parent and child perspectives on the nature of anxiety in children and young people with autism spectrum disorders: a focus group study. Autism. 2012 Mar;16(2):107–21. doi: 10.1177/1362361311431703. X-122297200
1311 Paden AR, Kodak T, Fisher WW, . Teaching children with autism to engage in peer-directed mands using a picture exchange communication system. J Appl Behav Anal. 2012 Summer;45(2):425–9. doi: 10.1901/jaba.2012.45-425. X-3, X-422844150
1312 Pajareya K, Nopmaneejumruslers K. A one-year prospective follow-up study of a DIR/Floortime parent training intervention for pre-school children with autistic spectrum disorders. J Med Assoc Thai. 2012 Sep;95(9):1184–93. X-323140036
1313 Palmen A, Didden R, Verhoeven L. A personal digital assistant for improving independent transitioning in adolescents with high-functioning autism spectrum disorder. Dev Neurorehabil. 2012;15(6):401–13. doi: 10.3109/17518423.2012.701240. X-1, X-3, X-423030628
1314 Palsbo SE, Hood-Szivek P. Effect of robotic-assisted three-dimensional repetitive motion to improve hand motor function and control in children with handwriting deficits: a nonrandomized phase 2 device trial. Am J Occup Ther. 2012 Nov–Dec;66(6):682–90. doi: 10.5014/ajot.2012.004556. X-3, X-423106988
1315 Pardini M, Elia M, Garaci FG, . Long-term cognitive and behavioral therapies, combined with augmentative communication, are related to uncinate fasciculus integrity in autism. J Autism Dev Disord. 2012 Apr;42(4):585–92. doi: 10.1007/s10803-011-1281-2. X-1, X-321573693
1316 Parish S, Thomas K, Rose R, . State insurance parity legislation for autism services and family financial burden. Intellect Dev Disabil. 2012 Jun;50(3):190–8. doi: 10.1352/1934-9556-50.3.190. X-122731968
1317 Park HY, Lin SC, Harwood RL, . Autism Intervention Research Programs of the Maternal and Child Health Bureau. Pediatrics. 2012 Nov;130(Suppl 2):S59–61. doi: 10.1542/peds.2012-0900B. X-1, X-223118254
1318 Park M. Pleasure, Throwing Breaches, and Embodied Metaphors: Tracing Transformations-in-Participation for a Child With Autism to a Sensory Integration-Based Therapy Session. OTJR (Thorofare N J). 2012 Winter;32(1):S34–47. doi: 10.3928/15394492-20110906-05. X-3, X-424650787
1319 Parsons MB, Reid DH, Bentley E, . Identifying indices of happiness and unhappiness among adults with autism: potential targets for behavioral assessment and intervention. Behav Anal Pract. 2012 Summer;5(1):15–25. X-123326627
1320 Paton B, Hohwy J, Enticott P. The Rubber Hand Illusion Reveals Proprioceptive and Sensorimotor Differences in Autism Spectrum Disorders. Journal of Autism & Developmental Disorders. 2012;42(9):1870–83 14p. doi: 10.1007/s10803-011-1430-7. Language: English. Entry Date: 20120824. Revision Date: 20150711. Publication Type: Journal Article. X-122189963
1321 Peacock G, Lin SC. Enhancing early identification and coordination of intervention services for young children with autism spectrum disorders: report from the Act Early Regional Summit Project. Disabil Health J. 2012 Jan;5(1):55–9. doi: 10.1016/j.dhjo.2011.10.001. X-122226299
1322 Pearson DA, Aman MG, Arnold LE, . High concordance of parent and teacher attention-deficit/hyperactivity disorder ratings in medicated and unmedicated children with autism spectrum disorders. J Child Adolesc Psychopharmacol. 2012 Aug;22(4):284–91. doi: 10.1089/cap.2011.0067. X-122849541
1323 Pearson GS. The transition experience of developmentally impaired young adults living in a structured apartment setting. ANS Adv Nurs Sci. 2012 Jul–Sep;35(3):E73–89. doi: 10.1097/ANS.0b013e31826261b4. X-122869219
1324 Pellicano E. The development of executive function in autism. Autism Res Treat. 2012;2012:146132. doi: 10.1155/2012/146132. X-122934168
1325 Pennesi CM, Klein LC. Effectiveness of the gluten-free, casein-free diet for children diagnosed with autism spectrum disorder: based on parental report. Nutr Neurosci. 2012 Mar;15(2):85–91. doi: 10.1179/1476830512y.0000000003. X-322564339
1326 Penrod B, Gardella L, Fernand J. An evaluation of a progressive high-probability instructional sequence combined with low-probability demand fading in the treatment of food selectivity. J Appl Behav Anal. 2012 Fall;45(3):527–37. doi: 10.1901/jaba.2012.45-527. X-3, X-423060666
1327 Pepin G, Stagnitti K. Come play with me: an argument to link autism spectrum disorders and anorexia nervosa through early childhood pretend play. Eat Disord. 2012;20(3):254–9. doi: 10.1080/10640266.2012.668488. X-122519903
1328 Perrin JM, Coury DL, Hyman SL, . Complementary and alternative medicine use in a large pediatric autism sample. Pediatrics. 2012 Nov;130(Suppl 2):S77–82. doi: 10.1542/peds.2012-0900E. X-123118257
1329 Perrin JM, Coury DL, Jones N, . The Autism Treatment Network and Autism Intervention Research Network on Physical Health: future directions. Pediatrics. 2012 Nov;130(Suppl 2):S198–201. doi: 10.1542/peds.2012-0900S. X-123118252
1330 Perry A. Autism beyond pediatrics: why bioethicists ought to rethink consent in light of chronicity and genetic identity. Bioethics. 2012 Jun;26(5):236–41. doi: 10.1111/j.1467-8519.2011.01952.x. X-122571426
1331 Peterson CC, Wellman HM, Slaughter V. The mind behind the message: advancing theory-of-mind scales for typically developing children, and those with deafness, autism, or Asperger syndrome. Child Dev. 2012 Mar–Apr;83(2):469–85. doi: 10.1111/j.1467-8624.2011.01728.x. X-122304467
1332 Peters-Scheffer N, Didden R, Korzilius H, . Cost comparison of early intensive behavioral intervention and treatment as usual for children with autism spectrum disorder in The Netherlands. Res Dev Disabil. 2012 Nov–Dec;33(6):1763–72. doi: 10.1016/j.ridd.2012.04.006. X-122705454
1333 Phi L, Ajaj R, Ramchandani MH, . Expanding the Grading of Recommendations Assessment, Development, and Evaluation (Ex-GRADE) for Evidence-Based Clinical Recommendations: Validation Study. Open Dent J. 2012;6:31–40. doi: 10.2174/1874210601206010031. X-122303416
1334 Pineda JA, Juavinett A, Datko M. Self-regulation of brain oscillations as a treatment for aberrant brain connections in children with autism. Med Hypotheses. 2012 Dec;79(6):790–8. doi: 10.1016/j.mehy.2012.08.031. X-122999736
1335 Polick AS, Carr JE, Hanney NM. A comparison of general and descriptive praise in teaching intraverbal behavior to children with autism. J Appl Behav Anal. 2012 Fall;45(3):593–9. doi: 10.1901/jaba.2012.45-593. X-1, X-3, X-423060672
1336 Pollard JS, Betz AM, Higbee TS. Script fading to promote unscripted bids for joint attention in children with autism. J Appl Behav Anal. 2012 Summer;45(2):387–93. doi: 10.1901/jaba.2012.45-387. X-3, X-422844144
1337 Ponsen MM, Stam CJ, Bosboom JL, . A three dimensional anatomical view of oscillatory resting-state activity and functional connectivity in Parkinson’s disease related dementia: An MEG study using atlas-based beamforming. Neuroimage Clin. 2012;2:95–102. doi: 10.1016/j.nicl.2012.11.007. X-124179762
1338 Pratt K, Baird G, Gringras P. Ensuring successful admission to hospital for young people with learning difficulties, autism and challenging behaviour: a continuous quality improvement and change management programme. Child Care Health Dev. 2012 Nov;38(6):789–97. doi: 10.1111/j.1365-2214.2011.01335.x. X-122017703
1339 Pringle B, Colpe LJ, Blumberg SJ, . Diagnostic history and treatment of school-aged children with autism spectrum disorder and special health care needs. NCHS Data Brief. 2012 May(97):1–8. X-1
1340 Randolph-Gips M, Srinivasan P. Modeling autism: a systems biology approach. J Clin Bioinforma. 2012;2(1):17. doi: 10.1186/2043-9113-2-17. X-123043674
1341 Raznahan A, Lenroot R, Thurm A, . Mapping cortical anatomy in preschool aged children with autism using surface-based morphometry. Neuroimage Clin. 2012;2:111–9. doi: 10.1016/j.nicl.2012.10.005. X-124179764
1342 Reaven J, Blakeley-Smith A, Culhane-Shelburne K, . Group cognitive behavior therapy for children with high-functioning autism spectrum disorders and anxiety: a randomized trial. J Child Psychol Psychiatry. 2012 Apr;53(4):410–9. X-122435114
1343 Reaven J, Blakeley-Smith A, Leuthe E, . Facing your fears in adolescence: cognitive-behavioral therapy for high-functioning autism spectrum disorders and anxiety. Autism Res Treat. 2012;2012:423905. doi: 10.1155/2012/423905. X-1, X-323091719
1344 Reed P. Brief Report: The Effect of Delayed Matching to Sample on Stimulus Over-Selectivity. Journal of Autism & Developmental Disorders. 2012;42(7):1515–9 5p. doi: 10.1007/s10803-011-1374-y. Language: English. Entry Date: 20120618. Revision Date: 20150711. Publication Type: Journal Article. X-121969076
1345 Reed P, McCarthy J. Cross-Modal Attention-Switching is Impaired in Autism Spectrum Disorders. Journal of Autism & Developmental Disorders. 2012;42(6):947–53 7p. doi: 10.1007/s10803-011-1324-8. Language: English. Entry Date: 20120604. Revision Date: 20150711. Publication Type: Journal Article. X-121720723
1346 Remington A, Campbell R, Swettenham J. Attentional status of faces for people with autism spectrum disorder. Autism: The International Journal of Research & Practice. 2012;16(1):59–73 15p. doi: 10.1177/1362361311409257. Language: English. Entry Date: 20120304. Revision Date: 20150711. Publication Type: Journal Article. X-121705475
1347 Riahi F, Izadi-Mazidi S. Comparison between the mental health of mothers of children with autism and control group. Iran J Psychiatry Behav Sci. 2012 Fall;6(2):91–5. X-124644488
1348 Rodriguez NM, Thompson RH, Schlichenmeyer K, . Functional analysis and treatment of arranging and ordering by individuals with an autism spectrum disorder. J Appl Behav Anal. 2012 Spring;45(1):1–22. doi: 10.1901/jaba.2012.45-1. X-122403446
1349 Rogers SJ, Estes A, Lord C, . Effects of a brief Early Start Denver model (ESDM)-based parent intervention on toddlers at risk for autism spectrum disorders: a randomized controlled trial. J Am Acad Child Adolesc Psychiatry. 2012 Oct;51(10):1052–65. doi: 10.1016/j.jaac.2012.08.003. X-123021480
1350 Roke Y, Buitelaar JK, Boot AM, . Risk of hyperprolactinemia and sexual side effects in males 10–20 years old diagnosed with autism spectrum disorders or disruptive behavior disorder and treated with risperidone. J Child Adolesc Psychopharmacol. 2012 Dec;22(6):432–9. doi: 10.1089/cap.2011.0109. X-1, X-323234586
1351 Roke Y, van Harten PN, Buitelaar JK, . Antipsychotic-induced hyperprolactinemia and testosterone levels in boys. Horm Res Paediatr. 2012;77(4):235–40. doi: 10.1159/000337910. X-122538969
1352 Roke Y, van Harten PN, Buitelaar JK, . Bone mineral density in male adolescents with autism spectrum disorders and disruptive behavior disorder with or without antipsychotic treatment. Eur J Endocrinol. 2012 Dec;167(6):855–63. doi: 10.1530/eje-12-0521. X-1, X-323011870
1353 Rose S, Melnyk S, Trusty TA, . Intracellular and extracellular redox status and free radical generation in primary immune cells from children with autism. Autism Res Treat. 2012;2012:986519. doi: 10.1155/2012/986519. X-122928106
1354 Rosenfeld D. The creation of the self and language: Primitive sensory relations of the child with the outside world. Karnac Books, London; 2012. p. 63-xv.
1355 Rosenfeld D. The creation of the self and language: Primitive sensory relations of the child with the outside world. 2012:63-xv; 2012-17258-000. X-1
1356 Rossignol DA, Bradstreet JJ, Van Dyke K, . Hyperbaric oxygen treatment in autism spectrum disorders. Med Gas Res. 2012;2(1):16. doi: 10.1186/2045-9912-2-16. X-122703610
1357 Rothenberg KG, Piadlo R, Nagaraj UD, . The complex picture test in dementia. Dement Geriatr Cogn Dis Extra. 2012 Jan;2(1):411–7. doi: 10.1159/000342349. X-123139686
1358 Roy JS, Datta PG. Autism spectrum disorder and detection of autism. Mymensingh Med J. 2012 Jan;21(1):188–9. X-122314481
1359 Ruble L, McGrew JH, Toland MD. Goal attainment scaling as an outcome measure in randomized controlled trials of psychosocial interventions in autism. J Autism Dev Disord. 2012 Sep;42(9):1974–83. doi: 10.1007/s10803-012-1446-7. X-122271197
1360 Russell B. Reflections on ‘autistic integrity’. Bioethics. 2012 Mar;26(3):164–70. doi: 10.1111/j.1467-8519.2010.01827.x. X-120497166
1361 Russo AJ, Bazin AP, Bigega R, . Plasma copper and zinc concentration in individuals with autism correlate with selected symptom severity. Nutr Metab Insights. 2012;5:41–7. doi: 10.4137/nmi.s8761. X-123882147
1362 Russo N, Mottron L, Burack JA, . Parameters of semantic multisensory integration depend on timing and modality order among people on the autism spectrum: evidence from event-related potentials. Neuropsychologia. 2012 Jul;50(9):2131–41. doi: 10.1016/j.neuropsychologia.2012.05.003. X-122613013
1363 Rutherford M, Troje N. IQ Predicts Biological Motion Perception in Autism Spectrum Disorders. Journal of Autism & Developmental Disorders. 2012;42(4):557–65 9p. doi: 10.1007/s10803-011-1267-0. Language: English. Entry Date: 20120509. Revision Date: 20150711. Publication Type: Journal Article. X-121538172
1364 Ryan S, Salisbury H. ‘You know what boys are like’: pre-diagnosis experiences of parents of children with autism spectrum conditions. Br J Gen Pract. 2012 May;62(598):e378–83. doi: 10.3399/bjgp12X641500. X-122546598
1365 Saalasti S, Katsyri J, Tiippana K, . Audiovisual speech perception and eye gaze behavior of adults with asperger syndrome. J Autism Dev Disord. 2012 Aug;42(8):1606–15. doi: 10.1007/s10803-011-1400-0. X-122068821
1366 Saalasti S, Tiippana K, Kätsyri J, . The effect of visual spatial attention on audiovisual speech perception in adults with Asperger syndrome: Erratum. Experimental Brain Research. 2012 2015-12-09;217(2):323. doi: http://dx.doi.org/10.1007/s00221-012-3029-4; 2012-04843-014. X-1
1367 Sakuma R, Gunji A, Goto T, . [Effectiveness of social skills training for children with developmental disorders: behavioral analysis using a two-dimensional motion capture system]. No To Hattatsu. 2012 Jul;44(4):320–6. X-1, X-3, X-422844765
1368 Salgueiro E, Nunes L, Barros A, . Effects of a dolphin interaction program on children with autism spectrum disorders: an exploratory research. BMC Res Notes. 2012;5:199. doi: 10.1186/1756-0500-5-199. X-1, X-3, X-422537536
1369 Salmanian M, Tehrani-Doost M, Ghanbari-Motlagh M, . Visual memory of meaningless shapes in children and adolescents with autism spectrum disorders. Iran J Psychiatry. 2012 Summer;7(3):104–8. X-123139690
1370 Sampanthavivat M, Singkhwa W, Chaiyakul T, . Hyperbaric oxygen in the treatment of childhood autism: a randomised controlled trial. Diving Hyperb Med. 2012 Sep;42(3):128–33.22987458
1371 Sanchez-Ponce R, Wang LQ, Lu W, . Metabolic and Pharmacokinetic Differentiation of STX209 and Racemic Baclofen in Humans. Metabolites. 2012;2(3):596–613. doi: 10.3390/metabo2030596. X-124957649
1372 Sauer C, Montag C, Worner C, . Effects of a common variant in the CD38 gene on social processing in an oxytocin challenge study: possible links to autism. Neuropsychopharmacology. 2012 May;37(6):1474–82. doi: 10.1038/npp.2011.333. X-122278094
1373 Sawicka K, Zukin RS. Dysregulation of mTOR signaling in neuropsychiatric disorders: therapeutic implications. Neuropsychopharmacology. 2012 Jan;37(1):305–6. doi: 10.1038/npp.2011.210. X-122157871
1374 Saylor S, Sidener TM, Reeve SA, . Effects of three types of noncontingent auditory stimulation on vocal stereotypy in children with autism. J Appl Behav Anal. 2012 Spring;45(1):185–90. doi: 10.1901/jaba.2012.45-185. X-3, X-422403464
1375 Scahill L, McCracken JT, Bearss K, . Design and subject characteristics in the federally-funded citalopram trial in children with pervasive developmental disorders. J Autism Dev Disord. 2012 Mar;42(3):432–40. doi: 10.1007/s10803-011-1251-8. X-121667200
1376 Scahill L, McDougle CJ, Aman MG, . Effects of risperidone and parent training on adaptive functioning in children with pervasive developmental disorders and serious behavioral problems. J Am Acad Child Adolesc Psychiatry. 2012 Feb;51(2):136–46. doi: 10.1016/j.jaac.2011.11.010. X-122265360
1377 Schaaf RC, Benevides TW, Kelly D, . Occupational therapy and sensory integration for children with autism: a feasibility, safety, acceptability and fidelity study. Autism. 2012 May;16(3):321–7. doi: 10.1177/1362361311435157. X-3, X-422318118
1378 Schaaf RC, Hunt J, Benevides T. Occupational Therapy Using Sensory Integration to Improve Participation of a Child With Autism: A Case Report. American Journal of Occupational Therapy. 2012;66(5):547–55 9p. doi: 10.5014/ajot.2012.004473. Language: English. Entry Date: 20121121. Revision Date: 20150819. Publication Type: Journal Article. X-3, X-422917121
1379 Schipul SE, Williams DL, Keller TA, . Distinctive neural processes during learning in autism. Cereb Cortex. 2012 Apr;22(4):937–50. doi: 10.1093/cercor/bhr162. X-121725037
1380 Schultz TR, Stichter JP, Herzog MJ, . Social Competence Intervention for Parents (SCI-P): Comparing Outcomes for a Parent Education Program Targeting Adolescents with ASD. Autism Res Treat. 2012;2012:681465. doi: 10.1155/2012/681465. X-122934178
1381 Segura Benedicto A. [The putative link between the MMR vaccine and autism and refusal to vaccinate]. Gac Sanit. 2012 Jul–Aug;26(4):366–71. doi: 10.1016/j.gaceta.2011.11.018. X-122444516
1382 Seiverling L, Williams K, Sturmey P, . Effects of behavioral skills training on parental treatment of children’s food selectivity. J Appl Behav Anal. 2012 Spring;45(1):197–203. doi: 10.1901/jaba.2012.45-197. X-3, X-422403466
1383 Sepeta L, Tsuchiya N, Davies MS, . Abnormal social reward processing in autism as indexed by pupillary responses to happy faces. J Neurodev Disord. 2012;4(1):17. doi: 10.1186/1866-1955-4-17. X-122958650
1384 Sequeira S, Ahmed M. Meditation as a potential therapy for autism: a review. Autism Res Treat. 2012;2012:835847. doi: 10.1155/2012/835847. X-1, X-222937260
1385 Severtson JM, Carr JE. Training novice instructors to implement errorless discrete-trial teaching: a sequential analysis. Behav Anal Pract. 2012 Winter;5(2):13–23. X-123730463
1386 Sharma A, Shaw SR. Efficacy of Risperidone in Managing Maladaptive Behaviors for Children With Autistic Spectrum Disorder: A Meta-Analysis. Journal of Pediatric Healthcare. 2012;26(4):291–9 9p. doi: 10.1016/j.pedhc.2011.02.008. Language: English. Entry Date: 20120725. Revision Date: 20150711. Publication Type: Journal Article. X-3
1387 Shield A, Meier RP. Palm reversal errors in native-signing children with autism. J Commun Disord. 2012 Nov–Dec;45(6):439–54. doi: 10.1016/j.jcomdis.2012.08.004. X-122981637
1388 Shields N, Muza R, Kosky C, . An Investigation into the Use of Stimulant Therapy during Pregnancy. Sleep Disord. 2012;2012:308952. doi: 10.1155/2012/308952. X-123470841
1389 Shogren KA, Plotner AJ. Transition planning for students with intellectual disability, autism, or other disabilities: data from the National Longitudinal Transition Study-2. Intellect Dev Disabil. 2012 Feb;50(1):16–30. doi: 10.1352/1934-9556-50.1.16. X-122316223
1390 Shumaker L. Love, autism style. Narrat Inq Bioeth. 2012 Winter;2(3):173–6. doi: 10.1353/nib.2012.0071. X-224406883
1391 Siaperas P, Ring HA, McAllister CJ, . Atypical movement performance and sensory integration in Asperger’s syndrome. Journal of Autism and Developmental Disorders. 2012 2015-12-09;42(5):718–25. doi: http://dx.doi.org/10.1007/s10803-011-1301-2; 2012-09914-007. X-121643861
1392 Siegel M. Psychopharmacology of autism spectrum disorder: evidence and practice. Child Adolesc Psychiatr Clin N Am. 2012 Oct;21(4):957–73. doi: 10.1016/j.chc.2012.07.006. X-1, X-223040909
1393 Siegel M, Beaulieu A. Psychotropic Medications in Children with Autism Spectrum Disorders: A Systematic Review and Synthesis for Evidence-Based Practice. Journal of Autism & Developmental Disorders. 2012;42(8):1592–605 14p. doi: 10.1007/s10803-011-1399-2. Language: English. Entry Date: 20120724. Revision Date: 20150711. Publication Type: Journal Article. X-1, X-222068820
1394 Siegel M, Doyle K, Chemelski B, . Specialized inpatient psychiatry units for children with autism and developmental disorders: a United States survey. J Autism Dev Disord. 2012 Sep;42(9):1863–9. doi: 10.1007/s10803-011-1426-3. X-122189962
1395 Silverman JL, Smith DG, Rizzo SJ, . Negative allosteric modulation of the mGluR5 receptor reduces repetitive behaviors and rescues social deficits in mouse models of autism. Sci Transl Med. 2012 Apr 25;4(131):131ra51. doi: 10.1126/scitranslmed.3003501. X-1
1396 Simpson EL. Comorbidity in Atopic Dermatitis. Curr Dermatol Rep. 2012 Mar 1;1(1):29–38. doi: 10.1007/s13671-011-0003-5. X-123745171
1397 Slocum SK, Miller SJ, Tiger JH. Using a blocked-trials procedure to teach identity matching to a child with autism. J Appl Behav Anal. 2012 Fall;45(3):619–24. doi: 10.1901/jaba.2012.45-619. X-1, X-3, X-423060677
1398 Smith LE, Maenner MJ, Seltzer MM. Developmental trajectories in adolescents and adults with autism: the case of daily living skills. J Am Acad Child Adolesc Psychiatry. 2012 Jun;51(6):622–31. doi: 10.1016/j.jaac.2012.03.001. X-122632621
1399 Smith T. Evolution of research on interventions for individuals with autism spectrum disorder: implications for behavior analysts. Behav Anal. 2012 Spring;35(1):101–13. X-122942539
1400 Snyder K, Higbee TS, Dayton E. Preliminary investigation of a video-based stimulus preference assessment. J Appl Behav Anal. 2012 Summer;45(2):413–8. doi: 10.1901/jaba.2012.45-413. X-1, X-3, X-422844148
1401 Sokhadze EM, Baruth JM, Sears L, . Prefrontal neuromodulation using rTMS improves error monitoring and correction function in autism. Appl Psychophysiol Biofeedback. 2012 Jun;37(2):91–102. doi: 10.1007/s10484-012-9182-5. X-122311204
1402 Sokhadze EM, Baruth JM, Sears L, . EVENT-RELATED POTENTIAL STUDY OF ATTENTION REGULATION DURING ILLUSORY FIGURE CATEGORIZATION TASK IN ADHD, AUTISM SPECTRUM DISORDER, AND TYPICAL CHILDREN. J Neurother. 2012;16(1):12–31. doi: 10.1080/10874208.2012.650119. X-123329879
1403 South M, Newton T, Chamberlain PD. Delayed reversal learning and association with repetitive behavior in autism spectrum disorders. Autism Res. 2012 Dec;5(6):398–406. doi: 10.1002/aur.1255. X-123097376
1404 Spencer MD, Chura LR, Holt RJ, . Failure to deactivate the default mode network indicates a possible endophenotype of autism. Mol Autism. 2012;3(1):15. doi: 10.1186/2040-2392-3-15. X-123206727
1405 Spencer MD, Holt RJ, Chura LR, . Atypical activation during the Embedded Figures Task as a functional magnetic resonance imaging endophenotype of autism. Brain: A Journal of Neurology. 2012;135(11):3469–80 12p. doi: brain/aws229. Language: English. Entry Date: 20130215. Revision Date: 20150711. Publication Type: Journal Article. X-123065480
1406 Stafstrom CE, Rho JM. The ketogenic diet as a treatment paradigm for diverse neurological disorders. Front Pharmacol. 2012;3:59. doi: 10.3389/fphar.2012.00059. X-1, X-222509165
1407 Stagnitti K, O’Connor C, Sheppard L. Impact of the Learn to Play program on play, social competence and language for children aged 5–8 years who attend a specialist school. Aust Occup Ther J. 2012 Aug;59(4):302–11. doi: 10.1111/j.1440-1630.2012.01018.x. X-3, X-422934903
1408 Stahmer AC, Suhrheinrich J, Reed S, . What works for you? Using teacher feedback to inform adaptations of pivotal response training for classroom use. Autism Res Treat. 2012;2012:709861. doi: 10.1155/2012/709861. X-1, X-223209896
1409 Stein BD, Sorbero MJ, Goswami U, . Impact of a private health insurance mandate on public sector autism service use in Pennsylvania. J Am Acad Child Adolesc Psychiatry. 2012 Aug;51(8):771–9. doi: 10.1016/j.jaac.2012.06.006. X-122840548
1410 Stein LI, Polido JC, Cermak SA. Oral care and sensory concerns in autism. Am J Occup Ther. 2012 Sep–Oct;66(5):e73–6. doi: 10.5014/ajot.2012.004085. X-122917131
1411 Stein LI, Polido JC, Najera SO, . Oral care experiences and challenges in children with autism spectrum disorders. Pediatr Dent. 2012 Sep–Oct;34(5):387–91. X-123211914
1412 Steiner A, Goldsmith T, Snow A, . Practitioner’s Guide to Assessment of Autism Spectrum Disorders in Infants and Toddlers. Journal of Autism & Developmental Disorders. 2012;42(6):1183–96 14p. doi: 10.1007/s10803-011-1376-9. Language: English. Entry Date: 20120604. Revision Date: 20150711. Publication Type: Journal Article. X-122057879
1413 Stigler KA, Mullett JE, Erickson CA, . Paliperidone for irritability in adolescents and young adults with autistic disorder. Psychopharmacology (Berl). 2012 Sep;223(2):237–45. doi: 10.1007/s00213-012-2711-3. X-122549762
1414 Storch EA, Arnold EB, Jones AM, . The role of co-occurring disruptive behavior in the clinical presentation of children and adolescents with anxiety in the context of autism spectrum disorders. Child Psychiatry Hum Dev. 2012 Oct;43(5):734–46. doi: 10.1007/s10578-012-0294-1. X-122407279
1415 Stratta P, de Cataldo S, Bonanni R, . Mental health in L’Aquila after the earthquake. Ann Ist Super Sanita. 2012;48(2):132–7. Doi: 10.4415/ann_12_02_05. X-122751555
1416 Strauss K, Vicari S, Valeri G, . Parent inclusion in Early Intensive Behavioral Intervention: the influence of parental stress, parent treatment fidelity and parent-mediated generalization of behavior targets on child outcomes. Res Dev Disabil. 2012 Mar–Apr;33(2):688–703. doi: 10.1016/j.ridd.2011.11.008. X-122188793
1417 Strauss LV. Comparing a narcissistic and an autistic retreat: ‘looking through or at the window’. Int J Psychoanal. 2012 Feb;93(1):97–116. doi: 10.1111/j.1745-8315.2011.00488.x. X-122320137
1418 Sturmey P. Treatment of psychopathology in people with intellectual and other disabilities. Canadian Journal of Psychiatry. 2012;57(10):593–600 8p. Language: English. Entry Date: 20130215. Revision Date: 20150712. Publication Type: Journal Article. X-1, X-223072950
1419 Suarez MA. Sensory processing in children with autism spectrum disorders and impact on functioning. Pediatric Clinics of North America. 2012;59(1):203–14 12p. Language: English. Entry Date: 20120413. Revision Date: 20150712. Publication Type: Journal Article. Journal Subset: Biomedical. X-122284803
1420 Tachibana Y, Green J, Hwang Y, . A systematic review with meta-analysis of comprehensive interventions for preschool children with autism spectrum disorder (ASD): study protocol. BMJ Open. 2012;2(2):e000679. doi: 10.1136/bmjopen-2011-000679. X-2
1421 Taheri A, Perry A. Exploring the proposed DSM-5 criteria in a clinical sample. J Autism Dev Disord. 2012 Sep;42(9):1810–7. doi: 10.1007/s10803-012-1599-4. X-122806000
1422 Talero-Gutierrez C, Rodriguez M, De La Rosa D, . [Profile of children and adolescents with autism spectrum disorders in an institution in Bogota, Colombia]. Neurologia. 2012 Mar;27(2):90–6. doi: 10.1016/j.nrl.2011.03.005. X-121592626
1423 Tanabe HC, Kosaka H, Saito DN, . Hard to “tune in”: neural mechanisms of live face-to-face interaction with high-functioning autistic spectrum disorder. Front Hum Neurosci. 2012;6:268. doi: 10.3389/fnhum.2012.00268. X-123060772
1424 Taylor BA, DeQuinzio JA. Observational learning and children with autism. Behav Modif. 2012 May;36(3):341–60. doi: 10.1177/0145445512443981. X-122569578
1425 Taylor JL, Warren ZE. Maternal depressive symptoms following autism spectrum diagnosis. J Autism Dev Disord. 2012 Jul;42(7):1411–8. doi: 10.1007/s10803-011-1375-x. X-121965086
1426 Tehrani-Doost M, Salmanian M, Ghanbari-Motlagh M, . Delayed face recognition in children and adolescents with autism spectrum disorders. Iran J Psychiatry. 2012 Spring;7(2):52–6. X-122952545
1427 Tellegen CL, Sanders MR. Using primary care parenting interventions to improve outcomes in children with developmental disabilities: a case report. Case Rep Pediatr. 2012;2012:150261. doi: 10.1155/2012/150261. X-2, X-3, X-422928141
1428 Thomas RH, Meeking MM, Mepham JR, . The enteric bacterial metabolite propionic acid alters brain and plasma phospholipid molecular species: further development of a rodent model of autism spectrum disorders. J Neuroinflammation. 2012;9:153. doi: 10.1186/1742-2094-9-153. X-122747852
1429 Tilford JM, Payakachat N, Kovacs E, . Preference-based health-related quality-of-life outcomes in children with autism spectrum disorders: a comparison of generic instruments. Pharmacoeconomics. 2012 Aug 1;30(8):661–79. doi: 10.2165/11597200-000000000-00000. X-122788258
1430 Tostes MH, Polonini HC, Gattaz WF, . Low serum levels of 25-hydroxyvitamin D (25-OHD) in children with autism. Trends Psychiatry Psychother. 2012 Sep;34(3):161–3. X-125923008
1431 Tsiouri I, Schoen Simmons E, Paul R. Enhancing the application and evaluation of a discrete trial intervention package for eliciting first words in preverbal preschoolers with ASD. J Autism Dev Disord. 2012 Jul;42(7):1281–93. doi: 10.1007/s10803-011-1358-y. X-3, X-421918912
1432 Turan MK, Moroz L, Croteau NP. Comparing the effectiveness of error-correction strategies in discrete trial training. Behav Modif. 2012 Mar;36(2):218–34. doi: 10.1177/0145445511427973. X-1, X-422133991
1433 Uno Y, Uchiyama T, Kurosawa M, . The combined measles, mumps, and rubella vaccines and the total number of vaccines are not associated with development of autism spectrum disorder: the first case-control study in Asia. Vaccine. 2012 Jun 13;30(28):4292–8. doi: 10.1016/j.vaccine.2012.01.093. X-122521285
1434 Vajawat M, Deepika PC. Comparative evaluation of oral hygiene practices and oral health status in autistic and normal individuals. J Int Soc Prev Community Dent. 2012 Jul;2(2):58–63. doi: 10.4103/2231-0762.109369. X-124478969
1435 Valenti M, Ciprietti T, Egidio C, . Adaptive Response of Children and Adolescents with Autism to the 2009 Earthquake in L’Aquila, Italy. Journal of Autism & Developmental Disorders. 2012;42(6):954–60 7p. doi: 10.1007/s10803-011-1323-9. Language: English. Entry Date: 20120604. Revision Date: 20150711. Publication Type: Journal Article. X-121717269
1436 Valentino AL, Shillingsburg MA, Call NA. Comparing the effects of echoic prompts and echoic prompts plus modeled prompts on intraverbal behavior. J Appl Behav Anal. 2012 Summer;45(2):431–5. doi: 10.1901/jaba.2012.45-431. X-1, X-3, X-422844151
1437 Valicenti-McDermott M, Hottinger K, Seijo R, . Age at diagnosis of autism spectrum disorders. J Pediatr. 2012 Sep;161(3):554–6. doi: 10.1016/j.jpeds.2012.05.012. X-122683037
1438 van der Meer L, Kagohara D, Achmadi D, . Speech-generating devices versus manual signing for children with developmental disabilities. Res Dev Disabil. 2012 Sep–Oct;33(5):1658–69. doi: 10.1016/j.ridd.2012.04.004. X-422554812
1439 van der Net J, Sprong MC. Commentary on ‘motor characteristics of young children referred for possible autism spectrum disorder’. Pediatric Physical Therapy. 2012 2012 Spring;24(1):30- 1p. Language: English. Entry Date: 20120406. Revision Date: 20150820. Publication Type: Journal Article. X-122207462
1440 Van der Poel J. The many questions of transition. Narrat Inq Bioeth. 2012 Winter;2(3):176–9. doi: 10.1353/nib.2012.0073. X-124406884
1441 Vandbakk M, Arntzen E, Gisnaas A, . Effect of training different classes of verbal behavior to decrease aberrant verbal behavior. Anal Verbal Behav. 2012;28(1):137–44. X-122754112
1442 Vande Wydeven K, Kwan A, Hardan AY, . Underutilization of genetics services for autism: the importance of parental awareness and provider recommendation. J Genet Couns. 2012 Dec;21(6):803–13. doi: 10.1007/s10897-012-9494-x. X-122415587
1443 Varni JW, Handen BL, Corey-Lisle PK, . Effect of aripiprazole 2 to 15 mg/d on health-related quality of life in the treatment of irritability associated with autistic disorder in children: a post hoc analysis of two controlled trials. Clin Ther. 2012 Apr;34(4):980–92. doi: 10.1016/j.clinthera.2012.02.023.22444782
1444 Varol E, Gaonkar B, Erus G, . FEATURE RANKING BASED NESTED SUPPORT VECTOR MACHINE ENSEMBLE FOR IMAGE CLASSIFICATION Proc IEEE Int Symp Biomed Imaging. 2012:146–9. doi: 10.1109/isbi.2012.6235505. X-123873289
1445 Veenstra-VanderWeele J. In this issue/abstract thinking: evolving picture of susceptibility factors in autism spectrum disorders. J Am Acad Child Adolesc Psychiatry. 2012 May;51(5):453–4. doi: 10.1016/j.jaac.2012.02.022. X-122525947
1446 Venker CE, McDuffie A, Ellis Weismer S, . Increasing verbal responsiveness in parents of children with autism:a pilot study. Autism. 2012 Nov;16(6):568–85. doi: 10.1177/1362361311413396. X-1, X-321846665
1447 Verglas M. [Managing unspoken pain]. Soins Psychiatr. 2012 Sep–Oct(282):33–6. X-123050361
1448 Verhoeven EW, Marijnissen N, Berger HJ, . Brief report: relationship between self-awareness of real-world behavior and treatment outcome in autism spectrum disorders. J Autism Dev Disord. 2012 May;42(5):889–94. doi: 10.1007/s10803-011-1311-0. X-121698498
1449 Verhoeven WM, Egger JI, Willemsen MH, . Phelan-McDermid syndrome in two adult brothers: atypical bipolar disorder as its psychopathological phenotype? Neuropsychiatr Dis Treat. 2012;8:175–9. doi: 10.2147/ndt.s30506. X-122570549
1450 Vernon TW, Koegel RL, Dauterman H, . An early social engagement intervention for young children with autism and their parents. J Autism Dev Disord. 2012 Dec;42(12):2702–17. doi: 10.1007/s10803-012-1535-7. X-3, X-422527708
1451 Vismara LA, Young GS, Rogers SJ. Telehealth for expanding the reach of early autism training to parents. Autism Res Treat. 2012;2012:121878. doi: 10.1155/2012/121878. X-1, X-323227334
1452 Vladescu JC, Carroll R, Paden A, . The effects of video modeling with voiceover instruction on accurate implementation of discrete-trial instruction. J Appl Behav Anal. 2012 Summer;45(2):419–23. doi: 10.1901/jaba.2012.45-419. X-122844149
1453 Vlasak E, Ezeani-Antwi R. EPILEPSY & AUTISM: The IMPORTANCE of MEDICATION MANAGEMENT. Exceptional Parent. 2012;42(8):32–4 3p. Language: English. Entry Date: 20130117. Revision Date: 20150711. Publication Type: Journal Article. X-1
1454 Waligorska A, Pisula E, Waligorski M, . AutismPro system in supporting treatment of children with autism in Poland. Pediatr Int. 2012 Oct;54(5):693–700. doi: 10.1111/j.1442-200X.2012.03637.x. X-3, X-422469462
1455 Walker HB. A true case story. Microb Ecol Health Dis. 2012;23 doi: 10.3402/mehd.v23i0.18985. X-1
1456 Wallace S, Fein D, Rosanoff M, . A global public health strategy for autism spectrum disorders. Autism Res. 2012 Jun;5(3):211–7. doi: 10.1002/aur.1236. X-122605577
1457 Wallen M, Joosten A. Weighted vests did not improve competing behaviours or joint attention of 2 year olds with Autism Spectrum Disorder ( ASD). Australian Occupational Therapy Journal. 2012;59(6):468–70 3p. doi: 10.1111/1440-1630.12014. Language: English. Entry Date: 20121128. Revision Date: 20150820. Publication Type: Journal Article. X-2, X-323174116
1458 Walton KM, Ingersoll BR. Evaluation of a Sibling-Mediated Imitation Intervention for Young Children with Autism. J Posit Behav Interv. 2012 Oct;14(4) doi: 10.1177/1098300712437044. X-3, X-4
1459 Wang J, Zhou X, Xia W, . Autism awareness and attitudes towards treatment in caregivers of children aged 3–6 years in Harbin, China. Soc Psychiatry Psychiatr Epidemiol. 2012 Aug;47(8):1301–8. doi: 10.1007/s00127-011-0438-9. X-122009414
1460 Wang J, Zhou X, Xia W, . Parent-reported health care expenditures associated with autism spectrum disorders in Heilongjiang province, China. BMC Health Serv Res. 2012;12:7. doi: 10.1186/1472-6963-12-7. X-122230043
1461 Warren Z, Taylor JL, McPheeters ML, . AHRQ Future Research Needs Papers. Future Research Needs: Interventions for Adolescents and Young Adults With Autism Spectrum Disorders: Identification of Future Research Needs From Comparative Effectiveness Review No. 65. Rockville (MD): Agency for Healthcare Research and Quality (US); 2012.
1462 Wasilewska J, Kaczmarski M, Stasiak-Barmuta A, . Low serum IgA and increased expression of CD23 on B lymphocytes in peripheral blood in children with regressive autism aged 3–6 years old. Arch Med Sci. 2012 May 9;8(2):324–31. doi: 10.5114/aoms.2012.28561. X-122662007
1463 Wehmeyer ML, Tasse MJ, Davies DK, . Support Needs of Adults with Intellectual Disability Across Domains: The Role of Technology. J Spec Educ Technol. 2012 Apr;27(2):11–22. X-125309010
1464 Wei H, Dobkin C, Sheikh AM, . The therapeutic effect of memantine through the stimulation of synapse formation and dendritic spine maturation in autism and fragile X syndrome. PLoS One. 2012;7(5):e36981. doi: 10.1371/journal.pone.0036981. X-122615862
1465 Weil TN, Inglehart MR. Three- to 21-year-old patients with autism spectrum disorders: parents’ perceptions of severity of symptoms, oral health, and oral health-related behavior. Pediatr Dent. 2012 Nov–Dec;34(7):473–9. X-123265164
1466 Weiss HR, Liu X, Grewal P, . Reduced effect of stimulation of AMPA receptors on cerebral O(2) consumption in a rat model of autism. Neuropharmacology. 2012 Oct;63(5):837–41. doi: 10.1016/j.neuropharm.2012.06.014. X-122722031
1467 Weiss K. So, what are you doing now? Narrat Inq Bioeth. 2012 Winter;2(3):E7–10. doi: 10.1353/nib.2012.0070. X-1, X-224406896
1468 Welterlin A, Turner-Brown LM, Harris S, . The home TEACCHing program for toddlers with autism. J Autism Dev Disord. 2012 Sep;42(9):1827–35. doi: 10.1007/s10803-011-1419-2. X-1, X-322160347
1469 Wentz E, Nyden A, Krevers B. Development of an internet-based support and coaching model for adolescents and young adults with ADHD and autism spectrum disorders: a pilot study. Eur Child Adolesc Psychiatry. 2012 Nov;21(11):611–22. doi: 10.1007/s00787-012-0297-2. X-122736195
1470 White H. TRIALS OF ANTIPSYCHOTIC DRUGS NEED TO BE IMPARTIAL. Nursing Standard. 2012;27(1):33- 1p. Language: English. Entry Date: 20120928. Revision Date: 20150711. Publication Type: Journal Article. X-1
1471 Whiteley P, Shattock P, Knivsberg AM, . Gluten- and casein-free dietary intervention for autism spectrum conditions. Front Hum Neurosci. 2012;6:344. doi: 10.3389/fnhum.2012.00344. X-223316152
1472 Whyatt C, Craig C. Motor Skills in Children Aged 7–10 Years, Diagnosed with Autism Spectrum Disorder. Journal of Autism & Developmental Disorders. 2012;42(9):1799–809 11p. doi: 10.1007/s10803-011-1421-8. Language: English. Entry Date: 20120824. Revision Date: 20150711. Publication Type: Journal Article. X-122180003
1473 Wiggins JL, Peltier SJ, Bedoyan JK, . The impact of serotonin transporter genotype on default network connectivity in children and adolescents with autism spectrum disorders. Neuroimage Clin. 2012;2:17–24. doi: 10.1016/j.nicl.2012.10.008. X-124179754
1474 Wild K, Poliakoff E, Jerrison A, . Goal-Directed and Goal-Less Imitation in Autism Spectrum Disorder. Journal of Autism & Developmental Disorders. 2012;42(8):1739–49 11p. doi: 10.1007/s10803-011-1417-4. Language: English. Entry Date: 20120724. Revision Date: 20150711. Publication Type: Journal Article. X-122146933
1475 Wilkinson KM, Light J. Preliminary Study of Gaze Toward Humans in Photographs by Individuals with Autism, Down Syndrome, or Other Intellectual Disabilities: Implications for Design of Visual Scene Displays. AAC: Augmentative & Alternative Communication. 2012;30(2):130–46 17p. doi: 10.3109/07434618.2014.904434. Language: English. Entry Date: 20140620. Revision Date: 20150819. Publication Type: Journal Article. X-1
1476 Williams BT, Gray KM, Tonge BJ. Teaching emotion recognition skills to young children with autism: a randomised controlled trial of an emotion training programme. J Child Psychol Psychiatry. 2012 Dec;53(12):1268–76. doi: 10.1111/j.1469-7610.2012.02593.x. X-122881991
1477 Williams K, Wray JA, Wheeler DM. Intravenous secretin for autism spectrum disorders (ASD). Cochrane Database of Systematic Reviews. 2012(4):N.PAG-N.PAG 1p. Language: English. Entry Date: 20100514. Revision Date: 20150711. Publication Type: Journal Article. X-2
1478 Williams PG, Tomchek S, Grau R, . Parent and physician perceptions of medical home care for children with autism spectrum disorders in the state of Kentucky. Clin Pediatr (Phila). 2012 Nov;51(11):1071–8. doi: 10.1177/0009922812460333. X-122984194
1479 Williams PG, Woods C, Stevenson M, . Psychotropic medication use in children with autism in the Kentucky Medicaid population. Clin Pediatr (Phila). 2012 Oct;51(10):923–7. doi: 10.1177/0009922812440837. X-122492834
1480 Williams SC. Genetics: Searching for answers. Nature. 2012 Nov 1;491(7422):S4–6. X-123136651
1481 Williamson E, Martin A. Psychotropic Medications in Autism: Practical Considerations for Parents. Journal of Autism & Developmental Disorders. 2012;42(6):1249–55 7p. doi: 10.1007/s10803-010-1144-2. Language: English. Entry Date: 20120604. Revision Date: 20150711. Publication Type: Journal Article. X-121170674
1482 Wong JD, Seltzer MM, Greenberg JS, . Stressful life events and daily stressors affect awakening cortisol level in midlife mothers of individuals with autism spectrum disorders. Aging Ment Health. 2012;16(8):939–49. doi: 10.1080/13607863.2012.688191. X-122640177
1483 Woodward JF, Swigonski NL, Ciccarelli MR. Assessing the health, functional characteristics, and health needs of youth attending a noncategorical transition support program. J Adolesc Health. 2012 Sep;51(3):272–8. doi: 10.1016/j.jadohealth.2011.12.016. X-122921138
1484 Wright SD, D’Astous V, Wright CA, . Grandparents of grandchildren with autism spectrum disorders (ASD): strengthening relationships through technology activities. Int J Aging Hum Dev. 2012;75(2):169–84. X-123185859
1485 Yamazaki H, Yamamoto R, Moroto S, . Cochlear implantation in children with congenital cytomegalovirus infection accompanied by psycho-neurological disorders. Acta Otolaryngol. 2012 Apr;132(4):420–7. doi: 10.3109/00016489.2011.653442. X-122443855
1486 Yang Y, Shen Y, Wu B. WITHDRAWN: Are there two different neural pathways for gender differences in autism spectrum disorders? - A pilot study. Med Hypotheses. 2012 Sep 11 doi: 10.1016/j.mehy.2012.08.015. X-1
1487 Yi L, Liu Y, Li Y, . Visual Scanning Patterns during the Dimensional Change Card Sorting Task in Children with Autism Spectrum Disorder. Autism Res Treat. 2012;2012:123053. doi: 10.1155/2012/123053. X-123050145
1488 Ying KC, Browne G, Hutchinson M, . Autism in Vietnam: the case for the development and evaluation of an information book to be distributed at the time of diagnosis. Issues Ment Health Nurs. 2012 May;33(5):288–92. doi: 10.3109/01612840.2011.653039. X-122545635
1489 Young RL, Posselt M. Using the transporters DVD as a learning tool for children with Autism Spectrum Disorders (ASD). J Autism Dev Disord. 2012 Jun;42(6):984–91. doi: 10.1007/s10803-011-1328-4. X-121822764
1490 Yui K. [Useful pharmacologic treatment in impaired social interaction in autism spectrum disorders]. Seishin Shinkeigaku Zasshi. 2012;114(8):934–40. X-1, X-223012855
1491 Yui K, Koshiba M, Nakamura S, . Effects of large doses of arachidonic acid added to docosahexaenoic acid on social impairment in individuals with autism spectrum disorders: a double-blind, placebo-controlled, randomized trial. J Clin Psychopharmacol. 2012 Apr;32(2):200–6. doi: 10.1097/JCP.0b013e3182485791. X-122370992
1492 Zhang R, Jia MX, Zhang JS, . Transcutaneous electrical acupoint stimulation in children with autism and its impact on plasma levels of arginine-vasopressin and oxytocin: a prospective single-blinded controlled study. Res Dev Disabil. 2012 Jul–Aug;33(4):1136–46. doi: 10.1016/j.ridd.2012.02.001. X-122502839
1493 Zimmer M, Desch L. Sensory Integration Therapies for Children With Developmental and Behavioral Disorders. Pediatrics. 2012;129(6):1186–9 4p. doi: 10.1542/peds.2012-0876. Language: English. Entry Date: 20120614. Revision Date: 20150712. Publication Type: Journal Article. X-1, X-222641765
1494 [Meeting minutes of the 1(st) developmental and behavioral pediatric summit forum in China]. Zhonghua Er Ke Za Zhi. 2013 Sep;51(9):713–4. X-124330999
1495 Supplement 2 - SYTAR 2013 Abstracts. Int J Yoga Therap. 2013 Jun;23(Suppl 2):54–62. X-1, X-2
1496 [Oxidative stress, rRNA genes, and antioxidant enzymes in pathogenesis of schizophrenia and autism: modeling and clinical advices]. Zh Obshch Biol. 2013 Sep–Oct;74(5):340–53. X-1
1497 Responses to sensory integration therapy challenges. OT Practice. 2013;18(6):23- 1p. Language: English. Entry Date: 20130607. Revision Date: 20150712. Publication Type: Journal Article. X-1
1498 Lay Abstracts. Autism: The International Journal of Research & Practice. 2013;17(2):242–5 4p. doi: 10.1177/1362361313481408. Language: English. Entry Date: 20130321. Revision Date: 20150711. Publication Type: Journal Article. X-1, X-2
1499 Noticeboard. Learning Disability Practice. 2013;16(7):14- 1p. Language: English. Entry Date: 20130909. Revision Date: 20150711. Publication Type: Journal Article. X-1
1500 Methylphenidate dosing improved behavior in children with ASD. Brown University Child & Adolescent Psychopharmacology Update. 2013;15(8):4–5 2p. Language: English. Entry Date: 20130805. Revision Date: 20150711. Publication Type: Journal Article. Journal Subset: Biomedical. X-1, X-2
1501 Use of valproate while pregnant increases child’s autism risk. Brown University Psychopharmacology Update. 2013;24(8):1–5 p. Language: English. Entry Date: 20130715. Revision Date: 20150711. Publication Type: Journal Article. Journal Subset: Biomedical. X-1, X-2
1502 Valproate linked to autism spectrum disorders. Nursing. 2013;43(7):10–1 2p. doi: 10.1097/01.NURSE.0000431141.28275.09. Language: English. Entry Date: 20130710. Revision Date: 20150820. Publication Type: Journal Article. X-1, X-2
1503 Clinical digest. Mothers’ prenatal use of antidepressants puts children at risk of autism. Nursing Standard. 2013;27(41):15- 1p. Language: English. Entry Date: 20130618. Revision Date: 20150819. Publication Type: Journal Article. X-1
1504 Clinical digest. Babies exposed to antiepileptic drug valproate in utero are more likely to develop autism. Nursing Standard. 2013;27(40):14–5 2p. Language: English. Entry Date: 20130610. Revision Date: 20150819. Publication Type: Journal Article. Journal Subset: Double Blind Peer Reviewed. X-1, X-2
1505 Intranasal oxytocin for boys with autism shows promise. Brown University Child & Adolescent Psychopharmacology Update. 2013;15(5):3–4 2p. Language: English. Entry Date: 20130429. Revision Date: 20150711. Publication Type: Journal Article. Journal Subset: Biomedical. X-1, X-2
1506 Fragile X syndrome study signals potential for acamprosate in autism. Brown University Child & Adolescent Psychopharmacology Update. 2013;15(4):1–3 p. Language: English. Entry Date: 20130403. Revision Date: 20150711. Publication Type: Journal Article. Journal Subset: Biomedical. X-1
1507 Long-term risperidone for young males linked to sexual effects. Brown University Child & Adolescent Psychopharmacology Update. 2013;15(3):3–4 2p. Language: English. Entry Date: 20130301. Revision Date: 20150711. Publication Type: Journal Article. Journal Subset: Biomedical. X-1, X-2
1508 News. Journal of Psychosocial Nursing & Mental Health Services. 2013;51(3):8–10 3p. doi: 10.3928/02793695-20130130-89. Language: English. Entry Date: 20130306. Revision Date: 20150711. Publication Type: Journal Article. X-1, X-2
1509 Hyperprolactinemia found in risperidonetreated youth. Brown University Child & Adolescent Psychopharmacology Update. 2013;15(2):4–5 2p. Language: English. Entry Date: 20130207. Revision Date: 20150711. Publication Type: Journal Article. Journal Subset: Biomedical. X-1, X-2
1510 Medication use in autistic youth examined. Brown University Child & Adolescent Psychopharmacology Update. 2013;15(1):7- 1p. Language: English. Entry Date: 20130104. Revision Date: 20150711. Publication Type: Journal Article. X-1, X-2
1511 Abisror Nm, Mekinian An, Lachassinne E, . Autism spectrum disorders in babies born to mothers with antiphospholipid syndrome. Seminars in Arthritis & Rheumatism. 2013;43(3):348–51 4p. doi: 10.1016/j.semarthrit.2013.07.001. Language: English. Entry Date: 20131219. Revision Date: 20150710. Publication Type: Journal Article. X-123910451
1512 Abu-Dahab S, Skidmore E, Holm M, . Motor and Tactile-Perceptual Skill Differences Between Individuals with High-Functioning Autism and Typically Developing Individuals Ages 5–21. Journal of Autism & Developmental Disorders. 2013;43(10):2241–8 8p. doi: 10.1007/s10803-011-1439-y. Language: English. Entry Date: 20130921. Revision Date: 20150711. Publication Type: Journal Article. X-122318760
1513 Adluru N, Hanlon BM, Lutz A, . Penalized likelihood phenotyping: unifying voxelwise analyses and multi-voxel pattern analyses in neuroimaging: penalized likelihood phenotyping. Neuroinformatics. 2013 Apr;11(2):227–47. doi: 10.1007/s12021-012-9175-9. X-123397550
1514 Ajzenman HF, Standeven JW, Shurtleff TL. Effect of hippotherapy on motor control, adaptive behaviors, and participation in children with autism spectrum disorder: a pilot study. Am J Occup Ther. 2013 Nov–Dec;67(6):653–63. doi: 10.5014/ajot.2013.008383. X-3, X-424195899
1515 Aksu F, Baykara B, Ergin C, . [Phenotypic features in autistic individuals: the finger length ratio (2D:4D), hair whorl, and hand dominance]. Turk Psikiyatri Derg. 2013 Summer;24(2):94–100. X-123754262
1516 Alaghband-Rad J, Nikvarz N, Tehrani-Doost M, . Memantine-induced speech problems in two patients with autistic disorder. Daru. 2013;21(1):54. doi: 10.1186/2008-2231-21-54. X-123819879
1517 Alant E, Zheng W, Harty M, . Translucency ratings of Blissymbols over repeated exposures by children with autism. Augment Altern Commun. 2013 Sep;29(3):272–83. doi: 10.3109/07434618.2013.813967. X-1, X-323902408
1518 Al-Ayadhi LY, Elamin NE. Camel Milk as a Potential Therapy as an Antioxidant in Autism Spectrum Disorder (ASD). Evid Based Complement Alternat Med. 2013;2013:602834. doi: 10.1155/2013/602834.24069051
1519 Aldbass AM, Bhat RS, El-Ansary A. Protective and therapeutic potency of N-acetyl-cysteine on propionic acid-induced biochemical autistic features in rats. J Neuroinflammation. 2013;10:42. doi: 10.1186/1742-2094-10-42. X-123537042
1520 Aldinger KA, Plummer JT, Levitt P. Comparative DNA methylation among females with neurodevelopmental disorders and seizures identifies TAC1 as a MeCP2 target gene. J Neurodev Disord. 2013;5(1):15. doi: 10.1186/1866-1955-5-15. X-123759142
1521 Al-Farsi YM, Waly MI, Deth RC, . Impact of nutrition on serum levels of docosahexaenoic acid among Omani children with autism. Nutrition. 2013 Sep;29(9):1142–6. doi: 10.1016/j.nut.2013.03.009. X-1, X-323800562
1522 Aljunied M, Frederickson N. Does central coherence relate to the cognitive performance of children with autism in dynamic assessments? Autism: The International Journal of Research & Practice. 2013;17(2):172–83 12p. doi: 10.1177/1362361311409960. Language: English. Entry Date: 20130321. Revision Date: 20150711. Publication Type: Journal Article. X-121715547
1523 Amato CA, Santos TH, Barbosa MR, . Longitudinal study of language therapy in 142 children and adolescents with autism spectrum disorders. Codas. 2013;25(4):388–90. X-1, X-324408489
1524 Ameis SH, Corbett-Dick P, Cole L, . Decision making and antipsychotic medication treatment for youth with autism spectrum disorders: applying guidelines in the real world. J Clin Psychiatry. 2013 Oct;74(10):1022–4. doi: 10.4088/JCP.13ac08691. X-124229756
1525 Anderson JS, Nielsen JA, Ferguson MA, . Abnormal brain synchrony in Down Syndrome. Neuroimage Clin. 2013;2:703–15. doi: 10.1016/j.nicl.2013.05.006. X-124179822
1526 Aoki Y, Abe O, Nippashi Y, . Comparison of white matter integrity between autism spectrum disorder subjects and typically developing individuals: a meta-analysis of diffusion tensor imaging tractography studies. Mol Autism. 2013;4(1):25. doi: 10.1186/2040-2392-4-25. X-123876131
1527 Apicella F, Chericoni N, Costanzo V, . Reciprocity in interaction: a window on the first year of life in autism. Autism Res Treat. 2013;2013:705895. doi: 10.1155/2013/705895. X-123762551
1528 Arber C, Li M. Cortical interneurons from human pluripotent stem cells: prospects for neurological and psychiatric disease. Front Cell Neurosci. 2013;7:10. doi: 10.3389/fncel.2013.00010. X-123493959
1529 Arvanitis H. Creating a Sensory Integration Gym in your Home. Exceptional Parent. 2013;43(4):30–2 3p. Language: English. Entry Date: 20130723. Revision Date: 20150711. Publication Type: Journal Article. X-1
1530 Asadabadi M, Mohammadi MR, Ghanizadeh A, . Celecoxib as adjunctive treatment to risperidone in children with autistic disorder: a randomized, double-blind, placebo-controlled trial. Psychopharmacology (Berl). 2013 Jan;225(1):51–9. doi: 10.1007/s00213-012-2796-8.22782459
1531 Asahi Y, Omichi S, Adachi S, . Ventilation via cut nasotracheal tube during general anesthesia. Anesth Prog. 2013 Spring;60(1):11–4. doi: 10.2344/11-00031.1. X-123506278
1532 Assaf M, Hyatt CJ, Wong CG, . Mentalizing and motivation neural function during social interactions in autism spectrum disorders. Neuroimage Clin. 2013;3:321–31. doi: 10.1016/j.nicl.2013.09.005. X-124273716
1533 Bachmann CJ, Manthey T, Kamp-Becker I, . Psychopharmacological treatment in children and adolescents with autism spectrum disorders in Germany. Res Dev Disabil. 2013 Sep;34(9):2551–63. doi: 10.1016/j.ridd.2013.05.028. X-1, X-323747941
1534 Baghdadli A, Brisot J, Henry V, . Social skills improvement in children with high-functioning autism: a pilot randomized controlled trial. Eur Child Adolesc Psychiatry. 2013 Jul;22(7):433–42. doi: 10.1007/s00787-013-0388-8. X-423417625
1535 Bainbridge J. Inducing labour may increase risk of autism. British Journal of Midwifery. 2013;21(11):828- 1p. Language: English. Entry Date: 20131112. Revision Date: 20150711. Publication Type: Journal Article. Journal Subset: Core Nursing. X-1
1536 Baker SM. Scientific narratives in autism spectrum disorder. Glob Adv Health Med. 2013 Nov;2(6):5. doi: 10.7453/gahmj.2013.095. X-1, X-2
1537 Baker SM, Milivojevich A. Gender differences among children with autism spectrum disorder: differential symptom patterns. Glob Adv Health Med. 2013 Nov;2(6):8–18. doi: 10.7453/gahmj.2013.003. X-1
1538 Bang J, Burns J, Nadig A. Brief report: Conveying subjective experience in conversation: production of mental state terms and personal narratives in individuals with high functioning autism. J Autism Dev Disord. 2013 Jul;43(7):1732–40. doi: 10.1007/s10803-012-1716-4. X-123179342
1539 Barker RM, Akaba S, Brady NC, . Support for AAC use in preschool, and growth in language skills, for young children with developmental disabilities. Augment Altern Commun. 2013 Dec;29(4):334–46. doi: 10.3109/07434618.2013.848933. X-1, X-324229337
1540 Barlow KE, Tiger JH, Slocum SK, . Comparing acquisition of exchange-based and signed mands with children with autism. Anal Verbal Behav. 2013;29(1):59–69. X-123814367
1541 Baron-Cohen S, Jaffa T, Davies S, . Do girls with anorexia nervosa have elevated autistic traits? Mol Autism. 2013;4(1):24. doi: 10.1186/2040-2392-4-24. X-123915495
1542 Bauer AZ, Kriebel D. Prenatal and perinatal analgesic exposure and autism: an ecological link. Environ Health. 2013;12:41. doi: 10.1186/1476-069x-12-41. X-123656698
1543 Bauman MD, Schumann CM. Is ‘bench-to-bedside’ realistic for autism? An integrative neuroscience approach. Neuropsychiatry (London). 2013 Apr;3(2):159–68. doi: 10.2217/npy.13.18. X-124000295
1544 Bauminger-Zviely N, Eden S, Zancanaro M, . Increasing social engagement in children with high-functioning autism spectrum disorder using collaborative technologies in the school environment. Autism. 2013 May;17(3):317–39. doi: 10.1177/1362361312472989. X-123614935
1545 Bay B, Mortensen EL, Hvidtjorn D, . Fertility treatment and risk of childhood and adolescent mental disorders: register based cohort study. Bmj. 2013;347:f3978. doi: 10.1136/bmj.f3978. X-123833075
1546 Bearss K, Johnson C, Handen B, . A pilot study of parent training in young children with autism spectrum disorders and disruptive behavior. J Autism Dev Disord. 2013 Apr;43(4):829–40. doi: 10.1007/s10803-012-1624-7. X-3, X-422941342
1547 Bearss K, Lecavalier L, Minshawi N, . Toward an exportable parent training program for disruptive behaviors in autism spectrum disorders. Neuropsychiatry (London). 2013 Apr;3(2):169–80. doi: 10.2217/npy.13.14. X-1, X-223772233
1548 Bebbington A, Glasson E, Bourke J, . Hospitalisation rates for children with intellectual disability or autism born in Western Australia 1983–1999: a population-based cohort study. BMJ Open. 2013;3(2) doi: 10.1136/bmjopen-2012-002356. X-1
1549 Bedford R, Gliga T, Frame K, . Failure to learn from feedback underlies word learning difficulties in toddlers at risk for autism. J Child Lang. 2013 Jan;40(1):29–46. doi: 10.1017/s0305000912000086. X-123217290
1550 Begeer S, Mandell D, Wijnker-Holmes B, . Sex differences in the timing of identification among children and adults with autism spectrum disorders. J Autism Dev Disord. 2013 May;43(5):1151–6. doi: 10.1007/s10803-012-1656-z. X-123001766
1551 Bekele ET, Lahiri U, Swanson AR, . A step towards developing adaptive robot-mediated intervention architecture (ARIA) for children with autism. IEEE Trans Neural Syst Rehabil Eng. 2013 Mar;21(2):289–99. doi: 10.1109/tnsre.2012.2230188. X-1, X-423221831
1552 Bekhet AK, Zauszniewski JA. Psychometric assessment of the depressive cognition scale among caregivers of persons with autism spectrum disorder. Arch Psychiatr Nurs. 2013 Apr;27(2):96–100. doi: 10.1016/j.apnu.2012.10.004. X-123540520
1553 Belmonte MK, Saxena-Chandhok T, Cherian R, . Oral motor deficits in speech-impaired children with autism. Front Integr Neurosci. 2013;7:47. doi: 10.3389/fnint.2013.00047. X-1, X-323847480
1554 Ben-Cheikh I, Rousseau C. [Autism and social support in recently immigrated families : experience of parents from Maghreb]. Sante Ment Que. 2013 Spring;38(1):189–205. X-124336996
1555 Bennett KD, Ramasamy R, Honsberger T. The effects of covert audio coaching on teaching clerical skills to adolescents with autism spectrum disorder. J Autism Dev Disord. 2013 Mar;43(3):585–93. doi: 10.1007/s10803-012-1597-6. X-122798051
1556 Bennett TA, Szatmari P, Bryson S, . Theory of Mind, Language and Adaptive Functioning in ASD: A Neuroconstructivist Perspective. J Can Acad Child Adolesc Psychiatry. 2013 Feb;22(1):13–9. X-123390428
1557 Ben-Sasson A, Lamash L, Gal E. To enforce or not to enforce? The use of collaborative interfaces to promote social skills in children with high functioning autism spectrum disorder. Autism. 2013 Sep;17(5):608–22. doi: 10.1177/1362361312451526. X-422987887
1558 Benvenuto A, Marciano S, Capuano I, . An update on autism spectrum disorders in children. Minerva Pediatr. 2013 Feb;65(1):19–36. X-123422571
1559 Berger DM. Tests, testing, and tested - we need to critically evaluate the meaning of tests in psychiatry. Indian J Psychiatry. 2013 Apr;55(2):200–3. doi: 10.4103/0019-5545.111466. X-123825862
1560 Bernier R, Aaronson B, McPartland J. The role of imitation in the observed heterogeneity in EEG mu rhythm in autism and typical development. Brain & Cognition. 2013;82(1):69–75 7p. doi: 10.1016/j.bandc.2013.02.008. Language: English. Entry Date: 20131101. Revision Date: 20150711. Publication Type: Journal Article. Journal Subset: Biomedical. X-123511847
1561 Bhatara A, Babikian T, Laugeson E, . Impaired Timing and Frequency Discrimination in High-functioning Autism Spectrum Disorders. Journal of Autism & Developmental Disorders. 2013;43(10):2312–28 17p. doi: 10.1007/s10803-013-1778-y. Language: English. Entry Date: 20130921. Revision Date: 20150711. Publication Type: Journal Article. X-123386117
1562 Bhatti I, Thome A, Smith PO, . A retrospective study of amitriptyline in youth with autism spectrum disorders. J Autism Dev Disord. 2013 May;43(5):1017–27. doi: 10.1007/s10803-012-1647-0. X-323135317
1563 Bilaver LA, Jordan N. Impact of state mental health parity laws on access to autism services. Psychiatr Serv. 2013 Oct;64(10):967–73. doi: 10.1176/appi.ps.201200411. X-123771517
1564 Billeci L, Sicca F, Maharatna K, . On the application of quantitative EEG for characterizing autistic brain: a systematic review. Front Hum Neurosci. 2013;7:442. doi: 10.3389/fnhum.2013.00442. X-1, X-223935579
1565 Black K, McCarus C, Collins ML, . Ocular manifestations of autism in ophthalmology. Strabismus. 2013 Jun;21(2):98–102. doi: 10.3109/09273972.2013.786733. X-123713930
1566 Blain-Moraes S, Chesser S, Kingsnorth S, . Biomusic: a novel technology for revealing the personhood of people with profound multiple disabilities. Augment Altern Commun. 2013 Jun;29(2):159–73. doi: 10.3109/07434618.2012.760648. X-123484489
1567 Bluth K, Roberson PN, Billen RM, . A Stress Model for Couples Parenting Children With Autism Spectrum Disorders and the Introduction of a Mindfulness Intervention. J Fam Theory Rev. 2013 Sep;5(3):194–213. doi: 10.1111/jftr.12015. X-124795780
1568 Bobo WV, Cooper WO, Stein CM, . Antipsychotics and the risk of type 2 diabetes mellitus in children and youth. JAMA Psychiatry. 2013 Oct;70(10):1067–75. doi: 10.1001/jamapsychiatry.2013.2053. X-123965896
1569 Boccuto L, Chen CF, Pittman AR, . Decreased tryptophan metabolism in patients with autism spectrum disorders. Mol Autism. 2013;4(1):16. doi: 10.1186/2040-2392-4-16. X-123731516
1570 Boesch MC, Wendt O, Subramanian A, . Comparative efficacy of the picture exchange communication system (PECS) versus a speech-generating device: effects on social-communicative skills and speech development. Augment Altern Commun. 2013 Sep;29(3):197–209. doi: 10.3109/07434618.2013.818059. X-3, X-423952565
1571 Bolte EE, Diehl JJ. Measurement tools and target symptoms/skills used to assess treatment response for individuals with autism spectrum disorder. J Autism Dev Disord. 2013 Nov;43(11):2491–501. doi: 10.1007/s10803-013-1798-7. x-123479074
1572 Boyd BA, Woodard CR, Bodfish JW. Feasibility of exposure response prevention to treat repetitive behaviors of children with autism and an intellectual disability: a brief report. Autism. 2013 Mar;17(2):196–204. doi: 10.1177/1362361311414066. X-3, X-421975037
1573 Bradley SJ. The importance of early intervention with children and youth in the autism spectrum. J Can Acad Child Adolesc Psychiatry. 2013 Aug;22(3):197–8. X-123970907
1574 Brandwein AB, Foxe JJ, Butler JS, . The development of multisensory integration in high-functioning autism: high-density electrical mapping and psychophysical measures reveal impairments in the processing of audiovisual inputs. Cereb Cortex. 2013 Jun;23(6):1329–41. doi: 10.1093/cercor/bhs109. X-122628458
1575 Breivik I, Hemmingsson H. Experiences of handwriting and using a computerized ATD in school: adolescents with Asperger’s syndrome. Scand J Occup Ther. 2013 Sep;20(5):349–56. doi: 10.3109/11038128.2012.748822. X-123312011
1576 Brent J. Commentary on the abuse of metal chelation therapy in patients with autism spectrum disorders. J Med Toxicol. 2013 Dec;9(4):370–2. doi: 10.1007/s13181-013-0345-4. X-124113859
1577 Breslin CM, Rudisill ME. Relationships Among Assessment Time, Time on Task, and Motor Skill Performance in Children With Autism Spectrum Disorder. Adapted Physical Activity Quarterly. 2013;30(4):338–50 13p. Language: English. Entry Date: 20131008. Revision Date: 20150819. Publication Type: Journal Article. X-124197623
1578 Brock J, Bzishvili S, Reid M, . Brief report: atypical neuromagnetic responses to illusory auditory pitch in children with autism spectrum disorders. J Autism Dev Disord. 2013 Nov;43(11):2726–31. doi: 10.1007/s10803-013-1805-z. X-1, X-423543291
1579 Brockevelt BL, Nissen R, Schweinle WE, . A comparison of the Sensory Profile scores of children with autism and an age- and gender-matched sample. S D Med. 2013 Nov;66(11):459, 61, 63–5. X-1
1580 Broder-Fingert S, Shui A, Pulcini CD, . Racial and ethnic differences in subspecialty service use by children with autism. Pediatrics. 2013 Jul;132(1):94–100. doi: 10.1542/peds.2012-3886. X-123776121
1581 Brogaard B. Serotonergic hyperactivity as a potential factor in developmental, acquired and drug-induced synesthesia. Frontiers in Human Neuroscience. 2013 2015-12-09;7; 2013-41426-001. X-1, X-223372547
1582 Brondino N, De Silvestri A, Re S, . A Systematic Review and Meta-Analysis of Ginkgo biloba in Neuropsychiatric Disorders: From Ancient Tradition to Modern-Day Medicine. Evid Based Complement Alternat Med. 2013;2013:915691. doi: 10.1155/2013/915691. X-1, X-223781271
1583 Buard I, Rogers SJ, Hepburn S, . Altered oscillation patterns and connectivity during picture naming in autism. Front Hum Neurosci. 2013;7:742. doi: 10.3389/fnhum.2013.00742. X-124265611
1584 Bucci MP, Doyen C, Contenjean Y, . The effect of performing a dual task on postural control in children with autism. ISRN Neurosci. 2013;2013:796174. doi: 10.1155/2013/796174. X-124959567
1585 Buon M, Dupoux E, Jacob P, . The Role of Causal and Intentional Judgments in Moral Reasoning in Individuals with High Functioning Autism. Journal of Autism & Developmental Disorders. 2013;43(2):458–70 13p. doi: 10.1007/s10803-012-1588-7. Language: English. Entry Date: 20130128. Revision Date: 20150711. Publication Type: Journal Article. X-122760338
1586 Burgess S, Audet L, Harjusola-Webb S. Quantitative and qualitative characteristics of the school and home language environments of preschool-aged children with ASD. J Commun Disord. 2013 Sep–Dec;46(5–6):428–39. doi: 10.1016/j.jcomdis.2013.09.003. X-124209428
1587 Burke RV, Allen KD, Howard MR, . Tablet-based video modeling and prompting in the workplace for individuals with autism. Journal of Vocational Rehabilitation. 2013;38(1):1–14 p. Language: English. Entry Date: 20130201. Revision Date: 20150819. Publication Type: Journal Article. X-1
1588 Burket JA, Benson AD, Tang AH, . D-Cycloserine improves sociability in the BTBR T+ Itpr3tf/J mouse model of autism spectrum disorders with altered Ras/Raf/ERK1/2 signaling. Brain Res Bull. 2013 Jul;96:62–70. doi: 10.1016/j.brainresbull.2013.05.003. X-123685206
1589 Butterly F, Percy C, Ward G. Brief report: do service dog providers placing dogs with children with developmental disabilities use outcome measures and, if so, what are they? J Autism Dev Disord. 2013 Nov;43(11):2720–5. doi: 10.1007/s10803-013-1803-1. X-1, X-323479076
1590 Buxbaum JD, Baron-Cohen S. DSM-5: the debate continues. Mol Autism. 2013;4(1):11. doi: 10.1186/2040-2392-4-11. X-323676181
1591 Cai Y, Chia NK, Thalmann D, . Design and development of a Virtual Dolphinarium for children with autism. IEEE Trans Neural Syst Rehabil Eng. 2013 Mar;21(2):208–17. doi: 10.1109/tnsre.2013.2240700. X-1, X-3, X-423362251
1592 Campbell NG, Zhu CB, Lindler KM, . Rare coding variants of the adenosine A3 receptor are increased in autism: on the trail of the serotonin transporter regulome. Mol Autism. 2013;4(1):28. doi: 10.1186/2040-2392-4-28. X-123953133
1593 Cannell JJ. Autism, will vitamin D treat core symptoms? Med Hypotheses. 2013 Aug;81(2):195–8. doi: 10.1016/j.mehy.2013.05.004. X-1, X-2, X-3, X-423725905
1594 Carbone PS, Murphy NA, Norlin C, . Parent and pediatrician perspectives regarding the primary care of children with autism spectrum disorders. J Autism Dev Disord. 2013 Apr;43(4):964–72. doi: 10.1007/s10803-012-1640-7. X-122948548
1595 Cascio CJ, Lorenzi J, Baranek GT. Self-reported Pleasantness Ratings and Examiner-Coded Defensiveness in Response to Touch in Children with ASD: Effects of Stimulus Material and Bodily Location. J Autism Dev Disord. 2013 Oct 5 doi: 10.1007/s10803-013-1961-1. X-1
1596 Casenhiser DM, Shanker SG, Stieben J. Learning through interaction in children with autism: preliminary data from asocial-communication-based intervention. Autism. 2013 Mar;17(2):220–41. doi: 10.1177/1362361311422052. X-121949005
1597 Cashin A, Browne G, Bradbury J, . The effectiveness of narrative therapy with young people with autism. J Child Adolesc Psychiatr Nurs. 2013 Feb;26(1):32–41. doi: 10.1111/jcap.12020. X-1, X-3, X-423351106
1598 Castro S, Ferreira T, Dababnah S, . Linking autism measures with the ICF-CY: functionality beyond the borders of diagnosis and interrater agreement issues. Dev Neurorehabil. 2013 Oct;16(5):321–31. doi: 10.3109/17518423.2012.733438. X-123869843
1599 Castro S, Pinto AI. Identification of core functioning features for assessment and intervention in Autism Spectrum Disorders. Disabil Rehabil. 2013 Jan;35(2):125–33. doi: 10.3109/09638288.2012.690494. X-122671037
1600 Catarino A, Andrade A, Churches O, . Task-related functional connectivity in autism spectrum conditions: an EEG study using wavelet transform coherence. Mol Autism. 2013;4(1):1. doi: 10.1186/2040-2392-4-1. X-123311570
1601 Cauffield JS. [INFOGRAPHIC] Medication use in autism spectrum disorders: What is the evidence? Formulary. 2013;48(5):1–10 p. Language: English. Entry Date: 20140715. Revision Date: 20150710. Publication Type: Journal Article. X-1, X-2
1602 Ceritoglu C, Tang X, Chow M, . Computational analysis of LDDMM for brain mapping. Front Neurosci. 2013;7:151. doi: 10.3389/fnins.2013.00151. X-123986653
1603 Chabout J, Cressant A, Hu X, . Making choice between competing rewards in uncertain vs. safe social environment: role of neuronal nicotinic receptors of acetylcholine. Front Hum Neurosci. 2013;7:468. doi: 10.3389/fnhum.2013.00468. X-123986674
1604 Chamberlain PD, Rodgers J, Crowley MJ, . A potentiated startle study of uncertainty and contextual anxiety in adolescents diagnosed with autism spectrum disorder. Mol Autism. 2013;4(1):31. doi: 10.1186/2040-2392-4-31. X-124007557
1605 Chan AS, Sze SL, Siu NY, . A chinese mind-body exercise improves self-control of children with autism: a randomized controlled trial. PLoS One. 2013;8(7):e68184. doi: 10.1371/journal.pone.0068184. X-123874533
1606 Charbonneau G, Bertone A, Lepore F, . Multilevel alterations in the processing of audio-visual emotion expressions in autism spectrum disorders. Neuropsychologia. 2013 Apr;51(5):1002–10. doi: 10.1016/j.neuropsychologia.2013.02.009. X-123462241
1607 Cheak-Zamora NC, Yang X, Farmer JE, . Disparities in transition planning for youth with autism spectrum disorder. Pediatrics. 2013 Mar;131(3):447–54. doi: 10.1542/peds.2012-1572. X-123400613
1608 Chebuhar A, McCarthy AM, Bosch J, . Using picture schedules in medical settings for patients with an autism spectrum disorder. J Pediatr Nurs. 2013 Apr;28(2):125–34. doi: 10.1016/j.pedn.2012.05.004. X-1, X-322742928
1609 Cheung G, Trembath D, Arciuli J, . The impact of workplace factors on evidence-based speech-language pathology practice for children with autism spectrum disorders. Int J Speech Lang Pathol. 2013 Aug;15(4):396–406. doi: 10.3109/17549507.2012.714797. X-122967045
1610 Chevallier C, Huguet P, Happé F, . Salient Social Cues are Prioritized in Autism Spectrum Disorders Despite Overall Decrease in Social Attention. Journal of Autism & Developmental Disorders. 2013;43(7):1642–51 10p. doi: 10.1007/s10803-012-1710-x. Language: English. Entry Date: 20130620. Revision Date: 20150711. Publication Type: Journal Article. X-123138729
1611 Chiang HM, Cheung YK, Li H, . Factors associated with participation in employment for high school leavers with autism. J Autism Dev Disord. 2013 Aug;43(8):1832–42. doi: 10.1007/s10803-012-1734-2. X-123224594
1612 Chiat S, Roy P. Early predictors of language and social communication impairments at ages 9–11 years: a follow-up study of early-referred children. J Speech Lang Hear Res. 2013 Dec;56(6):1824–36. doi: 10.1044/1092-4388(2013/12-0249). X-123926296
1613 Chien WH, Gau SS, Chen CH, . Increased gene expression of FOXP1 in patients with autism spectrum disorders. Mol Autism. 2013;4(1):23. doi: 10.1186/2040-2392-4-23. X-123815876
1614 Chien WH, Gau SS, Liao HM, . Deep exon resequencing of DLGAP2 as a candidate gene of autism spectrum disorders. Mol Autism. 2013;4(1):26. doi: 10.1186/2040-2392-4-26. X-123915500
1615 Christensen J, Gronborg TK, Sorensen MJ, . Prenatal valproate exposure and risk of autism spectrum disorders and childhood autism. Jama. 2013 Apr 24;309(16):1696–703. doi: 10.1001/jama.2013.2270. X-123613074
1616 Cidav Z, Lawer L, Marcus SC, . Age-related variation in health service use and associated expenditures among children with autism. J Autism Dev Disord. 2013 Apr;43(4):924–31. doi: 10.1007/s10803-012-1637-2. X-122941343
1617 Cividini-Motta C, Ahearn WH. Effects of two variations of differential reinforcement on prompt dependency. J Appl Behav Anal. 2013 Fall;46(3):640–50. doi: 10.1002/jaba.67. X-1, X-3, X-424114226
1618 Classen S, Monahan M, Brown KE, . Driving indicators in teens with attention deficit hyperactivity and/or autism spectrum disorder: Indicateurs de la conduite automobile chez les jeunes ayant un déficit de l’attention avec hyperactivité ou un trouble du spectre. Canadian Journal of Occupational Therapy. 2013;80(5):274–83 10p. doi: 10.1177/0008417413501072. Language: English. Entry Date: 20140225. Revision Date: 20150820. Publication Type: Journal Article. X-1
1619 Classen S, Monalian M, Wang V. Driving characteristics of teens with attention deficit hyperactivity and autism spectrum disorder. American Journal of Occupational Therapy. 2013 2016-06-17;67(6):664–73. doi: http://dx.doi.org/10.5014/ajot.2013.008821; 2013-41757-002. X-124195900
1620 Clay CJ, Samaha AL, Bloom SE, . Assessing preference for social interactions. Res Dev Disabil. 2013 Jan;34(1):362–71. doi: 10.1016/j.ridd.2012.07.028. X-1, X-423009945
1621 Clery H, Andersson F, Bonnet-Brilhault F, . fMRI investigation of visual change detection in adults with autism. Neuroimage Clin. 2013;2:303–12. doi: 10.1016/j.nicl.2013.01.010. X-124179785
1622 Clifford T, Minnes P. Logging on: evaluating an online support group for parents of children with autism spectrum disorders. J Autism Dev Disord. 2013 Jul;43(7):1662–75. doi: 10.1007/s10803-012-1714-6. X-123143075
1623 Clopper CG, Rohrbeck KL, Wagner L. Perception of talker age by young adults with high-functioning autism. J Autism Dev Disord. 2013 Jan;43(1):134–46. doi: 10.1007/s10803-012-1553-5. X-122638967
1624 Cofiel L, Bassi DU, Ray RK, . Detecting dissonance in clinical and research workflow for translational psychiatric registries. PLoS One. 2013;8(9):e75167. doi: 10.1371/journal.pone.0075167. X-124073246
1625 Cohen JA, Dickerson TA, Forbes JM. A legal review of autism, a syndrome rapidly gaining wide attention within our society. Albany Law Rev. 2013;77(2):389–423. X-124851321
1626 Collignon O, Charbonneau G, Peters F, . Reduced multisensory facilitation in persons with autism. Cortex: A Journal Devoted to the Study of the Nervous System & Behavior. 2013;49(6):1704–10 7p. doi: 10.1016/j.cortex.2012.06.001. Language: English. Entry Date: 20140131. Revision Date: 20150712. Publication Type: Journal Article. X-1, X-322818902
1627 Colver AF, Merrick H, Deverill M, . Study protocol: longitudinal study of the transition of young people with complex health needs from child to adult health services. BMC Public Health. 2013;13:675. doi: 10.1186/1471-2458-13-675. X-123875722
1628 Conner CM, Maddox BB, White SW. Parents’ state and trait anxiety: relationships with anxiety severity and treatment response in adolescents with autism spectrum disorders. J Autism Dev Disord. 2013 Aug;43(8):1811–8. doi: 10.1007/s10803-012-1728-0. X-123224592
1629 Cook JL, Blakemore S-J, Press C. Atypical basic movement kinematics in autism spectrum conditions. Brain: A Journal of Neurology. 2013;136(9):2816–24 9p. doi: brain/awt208. Language: English. Entry Date: 20131122. Revision Date: 20150711. Publication Type: Journal Article. X-123983031
1630 Corman MK. How mothers talk about placement of their child with autism outside the home. Qual Health Res. 2013 Oct;23(10):1320–32. doi: 10.1177/1049732313505225. X-124022735
1631 Coury DL. DSM-5 and autism spectrum disorders: implications for families and clinicians. J Dev Behav Pediatr. 2013 Sep;34(7):494–6. doi: 10.1097/DBP.0b013e31829cac3e. X-124042080
1632 Crippa A, Forti S, Perego P, . Eye-Hand Coordination in Children with High Functioning Autism and Asperger’s Disorder Using a Gap-Overlap Paradigm. Journal of Autism & Developmental Disorders. 2013;43(4):841–50 10p. doi: 10.1007/s10803-012-1623-8. Language: English. Entry Date: 20130321. Revision Date: 20150711. Publication Type: Journal Article. X-122865152
1633 Crowder SA, Merritte K. The possible therapeutic benefits of utilizing motion gaming systems on pediatric patients presenting autism. Tenn Med. 2013 Sep;106(8):41–3. X-5
1634 Curtin S, Vouloumanos A. Speech Preference is Associated with Autistic-Like Behavior in 18-Months-Olds at Risk for Autism Spectrum Disorder. Journal of Autism & Developmental Disorders. 2013;43(9):2114–20 7p. doi: 10.1007/s10803-013-1759-1. Language: English. Entry Date: 20130820. Revision Date: 20150711. Publication Type: Journal Article. X-123334808
1635 Daley TC, Singhal N, Krishnamurthy V. Ethical considerations in conducting research on autism spectrum disorders in low and middle income countries. J Autism Dev Disord. 2013 Sep;43(9):2002–14. doi: 10.1007/s10803-012-1750-2. X-123283629
1636 Dalsgaard S, Nielsen HS, Simonsen M. Five-fold increase in national prevalence rates of attention-deficit/hyperactivity disorder medications for children and adolescents with autism spectrum disorder, attention-deficit/hyperactivity disorder, and other psychiatric disorders: a Danish register-based study. J Child Adolesc Psychopharmacol. 2013 Sep;23(7):432–9. doi: 10.1089/cap.2012.0111. X-124015896
1637 Daniels AM, Mandell DS. Children’s compliance with American Academy of Pediatrics’ well-child care visit guidelines and the early detection of autism. J Autism Dev Disord. 2013 Dec;43(12):2844–54. doi: 10.1007/s10803-013-1831-x. X-123619952
1638 Davis TN, Dacus S, Strickland E, . Reduction of automatically maintained self-injurious behavior utilizing noncontingent matched stimuli. Dev Neurorehabil. 2013 Jun;16(3):166–71. doi: 10.3109/17518423.2013.766819. X-3, X-423477292
1639 de Boer-Schellekens L, Eussen M, Vroomen J. Diminished sensitivity of audiovisual temporal order in autism spectrum disorder. Front Integr Neurosci. 2013;7:8. doi: 10.3389/fnint.2013.00008. X-123450453
1640 de Boer-Schellekens L, Keetels M, Eussen M, . No evidence for impaired multisensory integration of low-level audiovisual stimuli in adolescents and young adults with autism spectrum disorders. Neuropsychologia. 2013 Dec;51(14):3004–13. doi: 10.1016/j.neuropsychologia.2013.10.005. X-124157536
1641 Deshpande G, Libero LE, Sreenivasan KR, . Identification of neural connectivity signatures of autism using machine learning. Front Hum Neurosci. 2013;7:670. doi: 10.3389/fnhum.2013.00670. X-124151458
1642 Dickerson M, Bae Y. Block copolymer nanoassemblies for photodynamic therapy and diagnosis. Ther Deliv. 2013 Nov;4(11):1431–41. doi: 10.4155/tde.13.105. X-124228992
1643 Domes G, Heinrichs M, Kumbier E, . Effects of intranasal oxytocin on the neural basis of face processing in autism spectrum disorder. Biol Psychiatry. 2013 Aug 1;74(3):164–71. doi: 10.1016/j.biopsych.2013.02.007. X-1, X-3, X-423510581
1644 Douglas JF, Sanders KB, Benneyworth MH, . Brief report: retrospective case series of oxcarbazepine for irritability/agitation symptoms in autism spectrum disorder. J Autism Dev Disord. 2013 May;43(5):1243–7. doi: 10.1007/s10803-012-1661-2. X-322976374
1645 Douglas SN, McNaughton D, Light J. Online Training for Paraeducators to Support the Communication of Young Children. Journal of Early Intervention. 2013;35(2):223–42 20p. doi: 10.1177/1053815114526782. Language: English. Entry Date: 20140110. Revision Date: 20150818. Publication Type: Journal Article. X-1
1646 Doyle-Thomas KA, Duerden EG, Taylor MJ, . Effects of age and symptomatology on cortical thickness in autism spectrum disorders. Res Autism Spectr Disord. 2013 Jan;7(1):141–50. doi: 10.1016/j.rasd.2012.08.004. X-123678367
1647 Dratsch T, Schwartz C, Yanev K, . Getting a Grip on Social Gaze: Control over Others’ Gaze Helps Gaze Detection in High-Functioning Autism. Journal of Autism & Developmental Disorders. 2013;43(2):286–300 15p. doi: 10.1007/s10803-012-1569-x. Language: English. Entry Date: 20130128. Revision Date: 20150711. Publication Type: Journal Article. X-122696196
1648 Dupere S, MacDonald RP, Ahearn WH. Using video modeling with substitutable loops to teach varied play to children with autism. J Appl Behav Anal. 2013 Fall;46(3):662–8. doi: 10.1002/jaba.68. X-1, X-3, X-424114229
1649 Durrleman S, Pennec X, Trouve A, . Toward a comprehensive framework for the spatiotemporal statistical analysis of longitudinal shape data. Int J Comput Vis. 2013 May;103(1):22–59. doi: 10.1007/s11263-012-0592-x. X-123956495
1650 Eack SM, Bahorik AL, Hogarty SS, . Brief report: is cognitive rehabilitation needed in verbal adults with autism? Insights from initial enrollment in a trial of cognitive enhancement therapy. J Autism Dev Disord. 2013 Sep;43(9):2233–7. doi: 10.1007/s10803-013-1774-2. X-123381484
1651 Eack SM, Greenwald DP, Hogarty SS, . Cognitive enhancement therapy for adults with autism spectrum disorder: results of an 18-month feasibility study. J Autism Dev Disord. 2013 Dec;43(12):2866–77. doi: 10.1007/s10803-013-1834-7. X-123619953
1652 Eapen V, Crncec R, Walter A. Clinical outcomes of an early intervention program for preschool children with Autism Spectrum Disorder in a community group setting. BMC Pediatr. 2013;13(1):3. doi: 10.1186/1471-2431-13-3. X-323294523
1653 Edvinsson D, Lindstrom E, Bingefors K, . Gender differences of axis I and II comorbidity in subjects diagnosed with attention-deficit hyperactivity disorder as adults. Acta Neuropsychiatr. 2013 Jun;25(3):165–74. doi: 10.1111/j.1601-5215.2012.00682.x. X-125287470
1654 Egan AM, Dreyer ML, Odar CC, . Obesity in young children with autism spectrum disorders: prevalence and associated factors. Child Obes. 2013 Apr;9(2):125–31. doi: 10.1089/chi.2012.0028. X-123485020
1655 Eigsti IM, Fein DA. More is less: pitch discrimination and language delays in children with optimal outcomes from autism. Autism Res. 2013 Dec;6(6):605–13. doi: 10.1002/aur.1324. X-123929787
1656 Eikeseth S, Smith DP. An analysis of verbal stimulus control in intraverbal behavior: implications for practice and applied research. Anal Verbal Behav. 2013;29(1):125–35. X-1, X-2, X-323814373
1657 El-Ansary A, Shaker G, Siddiqi NJ, . Possible ameliorative effects of antioxidants on propionic acid / clindamycin - induced neurotoxicity in Syrian hamsters. Gut Pathog. 2013;5(1):32. doi: 10.1186/1757-4749-5-32. X-124188374
1658 El-Ansary A, Shaker GH, El-Gezeery AR, . The neurotoxic effect of clindamycin - induced gut bacterial imbalance and orally administered propionic acid on DNA damage assessed by the comet assay: protective potency of carnosine and carnitine. Gut Pathog. 2013;5(1):9. doi: 10.1186/1757-4749-5-9. X-123587115
1659 Eldevik S, Ondire I, Hughes JC, . Effects of computer simulation training on in vivo discrete trial teaching. J Autism Dev Disord. 2013 Mar;43(3):569–78. doi: 10.1007/s10803-012-1593-x. X-122790382
1660 Ellis-Hervey N. The comparison of sensory integrative therapy (specifically weighted vests) and applied behavioral analysis (specifically a differential schedule of reinforcement) in the treatment of children who have autism spectrum disorder; 2013.
1661 Emerson A, Dearden J. Accommodating to motor difficulties and communication impairments in people with autism: the MORE intervention model. Front Integr Neurosci. 2013;7:45. doi: 10.3389/fnint.2013.00045. X-123785315
1662 Enticott PG, Kennedy HA, Rinehart NJ, . GABAergic activity in autism spectrum disorders: an investigation of cortical inhibition via transcranial magnetic stimulation. Neuropharmacology. 2013 May;68:202–9. doi: 10.1016/j.neuropharm.2012.06.017. X-122727823
1663 Eriksson MA, Westerlund J, Hedvall A, . Medical conditions affect the outcome of early intervention in preschool children with autism spectrum disorders. Eur Child Adolesc Psychiatry. 2013 Jan;22(1):23–33. doi: 10.1007/s00787-012-0312-7. X-122836733
1664 Esch JW, Mahoney AM, Kestner KM, . Echoic and self-echoic responses in children. Anal Verbal Behav. 2013;29(1):117–23. X-123814372
1665 Esposito G, Pasca SP. Motor abnormalities as a putative endophenotype for Autism Spectrum Disorders. Front Integr Neurosci. 2013;7:43. doi: 10.3389/fnint.2013.00043. X-123781177
1666 Essa MM, Subash S, Braidy N, . Role of NAD(+), Oxidative Stress, and Tryptophan Metabolism in Autism Spectrum Disorders. Int J Tryptophan Res. 2013;6(Suppl 1):15–28. doi: 10.4137/ijtr.s11355. X-123922500
1667 Estes A, Olson E, Sullivan K, . Parenting-related stress and psychological distress in mothers of toddlers with autism spectrum disorders. Brain Dev. 2013 Feb;35(2):133–8. doi: 10.1016/j.braindev.2012.10.004. X-123146332
1668 Fahmie TA, Iwata BA, Harper JM, . Evaluation of the divided attention condition during functional analyses. J Appl Behav Anal. 2013 Spring;46(1):71–8. doi: 10.1002/jaba.20. X-124114086
1669 Fahmy SF, El-hamamsy MH, Zaki OK, . L-Carnitine supplementation improves the behavioral symptoms in autistic children. Research in Autism Spectrum Disorders. 2013;7(1):159–66. doi: http://dx.doi.org/10.1016/j.rasd.2012.07.006; 2012-29769-018.
1670 Falter CM. Impaired and superior mirror symmetry perception in autism…Falter CM and Bailey AJ (2011) Perception of Mirror Symmetry in Autism Spectrum Disorder. Autism, published online first… Perreault A, Gurnsey R, Dawson M, Mottron L and Bertone A (2011) Increased sensitivity to mirror symmetry in autism. PLoS ONE 6(4): e19519. Autism: The International Journal of Research & Practice. 2013;17(1):117–8 2p. doi: 10.1177/1362361312438618. Language: English. Entry Date: 20130226. Revision Date: 20150711. Publication Type: Journal Article. X-123045219
1671 Farlow MR, Schmitt F, Aarsland D, . Comparing clinical profiles in Alzheimer’s disease and Parkinson’s disease dementia. Dement Geriatr Cogn Dis Extra. 2013;3(1):281–90. doi: 10.1159/000351861. X-124174923
1672 Farmer C, Thurm A, Grant P. Pharmacotherapy for the Core Symptoms in Autistic Disorder: Current Status of the Research. Drugs. 2013;73(4):303–14 12p. doi: 10.1007/s40265-013-0021-7. Language: English. Entry Date: 20130416. Revision Date: 20150711. Publication Type: Journal Article. X-223504356
1673 Fatemi SH, Folsom TD, Kneeland RE, . Impairment of fragile X mental retardation protein-metabotropic glutamate receptor 5 signaling and its downstream cognates ras-related C3 botulinum toxin substrate 1, amyloid beta A4 precursor protein, striatal-enriched protein tyrosine phosphatase, and homer 1, in autism: a postmortem study in cerebellar vermis and superior frontal cortex. Mol Autism. 2013;4(1):21. doi: 10.1186/2040-2392-4-21. X-123803181
1674 Favre MR, Barkat TR, Lamendola D, . General developmental health in the VPA-rat model of autism. Front Behav Neurosci. 2013;7:88. doi: 10.3389/fnbeh.2013.00088. X-123898245
1675 Feinberg E, Silverstein M, Ferreira-Cesar Z. Integrating mental health services for mothers of children with autism. Psychiatr Serv. 2013 Sep 1;64(9):930. doi: 10.1176/appi.ps.640603. X-124026841
1676 Fereshtehnejad SM, Religa D, Westman E, . Demography, diagnostics, and medication in dementia with Lewy bodies and Parkinson’s disease with dementia: data from the Swedish Dementia Quality Registry (SveDem). Neuropsychiatr Dis Treat. 2013;9:927–35. doi: 10.2147/ndt.s45840. X-123847419
1677 Fernandez-Jaen A, Fernandez-Mayoralas DM, Calleja-Perez B, . Efficacy of atomoxetine for the treatment of ADHD symptoms in patients with pervasive developmental disorders: a prospective, open-label study. J Atten Disord. 2013 Aug;17(6):497–505. doi: 10.1177/1087054711423626. X-1, X-322366240
1678 Fernell E, Eriksson MA, Gillberg C. Early diagnosis of autism and impact on prognosis: a narrative review. Clin Epidemiol. 2013;5:33–43. doi: 10.2147/clep.s41714. X-1, X-223459124
1679 Fernell E, Landgren M, Lindstrom K, . [Children and young people with neurodevelopmental problems: Support and efforts must be given even if not all diagnostic criteria are met]. Lakartidningen. 2013 Sep 18–24;110(38):1674. X-124199445
1680 Finucane B, Haas-Givler B, Simon EW. Knowledge and perceptions about fragile X syndrome: implications for diagnosis, intervention, and research. Intellect Dev Disabil. 2013 Aug;51(4):226–36. doi: 10.1352/1934-9556-51.4.226. X-123909584
1681 Fisher WW, Rodriguez NM, Owen TM. Functional assessment and treatment of perseverative speech about restricted topics in an adolescent with Asperger syndrome. J Appl Behav Anal. 2013 Spring;46(1):307–11. doi: 10.1002/jaba.19. X-124114104
1682 Fitzpatrick P, Diorio R, Richardson MJ, . Dynamical methods for evaluating the time-dependent unfolding of social coordination in children with autism. Front Integr Neurosci. 2013;7:21. doi: 10.3389/fnint.2013.00021. X-123580133
1683 Flechas J. Jorge Flechas, MD: the potential of oxytocin, nitric oxide, and iodine. Altern Ther Health Med. 2013 Jul–Aug;19(4):50–6. X-1, X-2
1684 Foster L, Dunn W, Lawson LM. Coaching mothers of children with autism: a qualitative study for occupational therapy practice. Phys Occup Ther Pediatr. 2013 May;33(2):253–63. doi: 10.3109/01942638.2012.747581. X-123253014
1685 Foxx RM. The maintenance of behavioral change: the case for long-term follow-ups. Am Psychol. 2013 Nov;68(8):728–36. doi: 10.1037/a0033713. X-1, X-224320663
1686 Frances A, Batstra L. Why so many epidemics of childhood mental disorder? J Dev Behav Pediatr. 2013 May;34(4):291–2. doi: 10.1097/DBP.0b013e31829425f5. X-123669874
1687 Franco JH, Davis BL, Davis JL. Increasing social interaction using prelinguistic milieu teaching with nonverbal school-age children with autism. Am J Speech Lang Pathol. 2013 Aug;22(3):489–502. doi: 10.1044/1058-0360(2012/10-0103). X-3, X-423813208
1688 Freitag CM, Cholemkery H, Elsuni L, . The group-based social skills training SOSTA-FRA in children and adolescents with high functioning autism spectrum disorder--study protocol of the randomised, multi-centre controlled SOSTA--net trial. Trials. 2013;14:6. doi: 10.1186/1745-6215-14-6. X-223289935
1689 Frenette P, Dodds L, MacPherson K, . Factors affecting the age at diagnosis of autism spectrum disorders in Nova Scotia, Canada. Autism. 2013 Mar;17(2):184–95. doi: 10.1177/1362361311413399. X-121788254
1690 Frye RE, DeLatorre R, Taylor HB, . Metabolic effects of sapropterin treatment in autism spectrum disorder: a preliminary study. Transl Psychiatry. 2013;3:e237. doi: 10.1038/tp.2013.14. X-3, X-423462988
1691 Frye RE, Melnyk S, Fuchs G, . Effectiveness of methylcobalamin and folinic Acid treatment on adaptive behavior in children with autistic disorder is related to glutathione redox status. Autism Res Treat. 2013;2013:609705. doi: 10.1155/2013/609705. X-324224089
1692 Frye RE, Sequeira JM, Quadros EV, . Cerebral folate receptor autoantibodies in autism spectrum disorder. Mol Psychiatry. 2013 Mar;18(3):369–81. doi: 10.1038/mp.2011.175. X-1, X-322230883
1693 Gal E, Ben Meir A, Katz N. Development and reliability of the Autism Work Skills Questionnaire (AWSQ). Am J Occup Ther. 2013 Jan–Feb;67(1):e1–5. doi: 10.5014/ajot.2013.005066. X-123245792
1694 Gan SM, Tung LC, Yeh CY, . ICF-CY based assessment tool for children with autism. Disabil Rehabil. 2013 Apr;35(8):678–85. doi: 10.3109/09638288.2012.705946. X-1, X-322897818
1695 Ganz JB, Goodwyn FD, Boles MM, . Impacts of a PECS instructional coaching intervention on practitioners and children with autism. Augment Altern Commun. 2013 Sep;29(3):210–21. doi: 10.3109/07434618.2013.818058. X-123952566
1696 Garcia-Penas JJ, Carreras-Saaez I. [Autism, epilepsy and tuberous sclerosis complex: a functional model linked to mTOR pathway]. Rev Neurol. 2013 Feb 22;56(Suppl 1):S153–61. X-123446718
1697 Gay V, Leijdekkers P, Wong F. Using sensors and facial expression recognition to personalize emotion learning for autistic children. Stud Health Technol Inform. 2013;189:71–6. X-523739360
1698 Geier DA, Hooker BS, Kern JK, . A two-phase study evaluating the relationship between Thimerosal-containing vaccine administration and the risk for an autism spectrum disorder diagnosis in the United States. Transl Neurodegener. 2013;2(1):25. doi: 10.1186/2047-9158-2-25. X-124354891
1699 Geier DA, Kern JK, Geier MR. A Comparison of the Autism Treatment Evaluation Checklist (ATEC) and the Childhood Autism Rating Scale (CARS) for the Quantitative Evaluation of Autism. J Ment Health Res Intellect Disabil. 2013 Oct;6(4):255–67. doi: 10.1080/19315864.2012.681340. X-123914277
1700 Gelder Bd, Stienen BMC, Stock JVd. Emotions by ear and by eye. Integrating face and voice in person perception.: Springer Science + Business Media, New York, NY; 2013:253–68.
1701 Gentile I, Bravaccio C, Bonavolta R, . Response to measles-mumps-rubella vaccine in children with autism spectrum disorders. In Vivo. 2013 May–Jun;27(3):377–82. X-123606694
1702 Georgescu AL, Kuzmanovic B, Schilbach L, . Neural correlates of “social gaze” processing in high-functioning autism under systematic variation of gaze duration. Neuroimage Clin. 2013;3:340–51. doi: 10.1016/j.nicl.2013.08.014. X-124273718
1703 Ghaleiha A, Asadabadi M, Mohammadi MR, . Memantine as adjunctive treatment to risperidone in children with autistic disorder: a randomized, double-blind, placebo-controlled trial. Int J Neuropsychopharmacol. 2013 May;16(4):783–9. doi: 10.1017/s1461145712000880.22999292
1704 Ghaleiha A, Ghyasvand M, Mohammadi MR, . Galantamine efficacy and tolerability as an augmentative therapy in autistic children: A randomized, double-blind, placebo-controlled trial. J Psychopharmacol. 2013 Oct 15;28(7):677–85. doi: 10.1177/0269881113508830.24132248
1705 Ghaleiha A, Mohammadi E, Mohammadi MR, . Riluzole as an adjunctive therapy to risperidone for the treatment of irritability in children with autistic disorder: a double-blind, placebo-controlled, randomized trial. Paediatr Drugs. 2013 Dec;15(6):505–14. doi: 10.1007/s40272-013-0036-2.23821414
1706 Ghanizadeh A, Moghimi-Sarani E. A randomized double blind placebo controlled clinical trial of N-Acetylcysteine added to risperidone for treating autistic disorders. BMC Psychiatry. 2013;13:196. doi: 10.1186/1471-244x-13-196.23886027
1707 Ghezzo A, Visconti P, Abruzzo PM, . Oxidative Stress and Erythrocyte Membrane Alterations in Children with Autism: Correlation with Clinical Features. PLoS One. 2013;8(6):e66418. doi: 10.1371/journal.pone.0066418. X-123840462
1708 Giallo R, Wood CE, Jellett R, . Fatigue, wellbeing and parental self-efficacy in mothers of children with an autism spectrum disorder. Autism. 2013 Jul;17(4):465–80. doi: 10.1177/1362361311416830. X-121788255
1709 Gibbard CR, Ren J, Seunarine KK, . White matter microstructure correlates with autism trait severity in a combined clinical-control sample of high-functioning adults. Neuroimage Clin. 2013;3:106–14. doi: 10.1016/j.nicl.2013.07.007. X-124179854
1710 Gillies D, Carroll L, Loos M. Commentary on ‘Social skills groups for people aged 6 to 21 with autism spectrum disorders (ASD)’. Evid Based Child Health. 2013 Mar 7;8(2):316–7. doi: 10.1002/ebch.1902. X-123877885
1711 Goldknopf EJ. Atypical resource allocation may contribute to many aspects of autism. Front Integr Neurosci. 2013;7:82. doi: 10.3389/fnint.2013.00082. X-124421760
1712 Golubchik P, Sever J, Weizman A. Reboxetine treatment for autistic spectrum disorder of pediatric patients with depressive and inattentive/hyperactive symptoms: an open-label trial. Clin Neuropharmacol. 2013 Mar–Apr;36(2):37–41. doi: 10.1097/WNF.0b013e31828003c1. X-3, X-423503544
1713 Gonzalez C, Martin J, Minshew N, . Practice Makes Improvement: How Adults with Autism Out-Perform Others in a Naturalistic Visual Search Task. Journal of Autism & Developmental Disorders. 2013;43(10):2259–68 10p. doi: 10.1007/s10803-013-1772-4. Language: English. Entry Date: 20130921. Revision Date: 20150711. Publication Type: Journal Article. X-123381483
1714 Goods KS, Ishijima E, Chang YC, . Preschool based JASPER intervention in minimally verbal children with autism: pilot RCT. J Autism Dev Disord. 2013 May;43(5):1050–6. doi: 10.1007/s10803-012-1644-3. X-122965298
1715 Goral M, Conner PS. Language Disorders in Multilingual and Multicultural Populations. Annu Rev Appl Linguist. 2013 Mar;33:128–61. doi: 10.1017/s026719051300010x. X-126257455
1716 Gordon I, Vander Wyk BC, Bennett RH, . Oxytocin enhances brain function in children with autism. Proc Natl Acad Sci U S A. 2013 Dec 24;110(52):20953–8. doi: 10.1073/pnas.1312857110. X-3, X-424297883
1717 Gowen E, Hamilton A. Motor Abilities in Autism: A Review Using a Computational Context. Journal of Autism & Developmental Disorders. 2013;43(2):323–44 22p. doi: 10.1007/s10803-012-1574-0. Language: English. Entry Date: 20130128. Revision Date: 20150711. Publication Type: Journal Article. X-122723127
1718 Graf-Myles J, Farmer C, Thurm A, . Dietary adequacy of children with autism compared with controls and the impact of restricted diet. J Dev Behav Pediatr. 2013 Sep;34(7):449–59. doi: 10.1097/DBP.0b013e3182a00d17. X-124042076
1719 Granovetter M. Let’s talk therapy: treatments for children with autism. Lancet. 2013 Aug 31;382(9894):753. doi: 10.1016/s0140-6736(13)61677-3. X-123993177
1720 Grant R, Nozyce M. Proposed changes to the American Psychiatric Association diagnostic criteria for autism spectrum disorder: implications for young children and their families. Matern Child Health J. 2013 May;17(4):586–92. doi: 10.1007/s10995-013-1250-9. X-123456348
1721 Grecucci A, Brambilla P, Siugzdaite R, . Emotional Resonance Deficits in Autistic Children. Journal of Autism & Developmental Disorders. 2013;43(3):616–28 13p. doi: 10.1007/s10803-012-1603-z. Language: English. Entry Date: 20130225. Revision Date: 20150711. Publication Type: Journal Article. X-122806001
1722 Green J, Wan MW, Guiraud J, . Intervention for infants at risk of developing autism: a case series. J Autism Dev Disord. 2013 Nov;43(11):2502–14. doi: 10.1007/s10803-013-1797-8. X-1, X-323532347
1723 Greener M. Research roundup: June 2013. Nurse Prescribing. 2013;11(6):270–1 2p. Language: English. Entry Date: 20130802. Revision Date: 20150818. Publication Type: Journal Article. X-1
1724 Green-Hennessy S. Coverage of mental health and substance misuse topics in the Cochrane review system. Epidemiol Psychiatr Sci. 2013 Jun;22(2):155–62. doi: 10.1017/s2045796012000455. X-123089060
1725 Grether JK, Qian Y, Croughan MS, . Is infertility associated with childhood autism? J Autism Dev Disord. 2013 Mar;43(3):663–72. doi: 10.1007/s10803-012-1598-5. X-122777105
1726 Grigg-Damberger M, Ralls F. Treatment strategies for complex behavioral insomnia in children with neurodevelopmental disorders. Current Opinion in Pulmonary Medicine. 2013;19(6):616–25 10p. doi: 10.1097/MCP.0b013e328365ab89. Language: English. Entry Date: 20140613. Revision Date: 20150712. Publication Type: Journal Article. X-124055857
1727 Grossman M, Peskin J, San Juan V. Thinking About a Reader’s Mind: Fostering Communicative Clarity in the Compositions of Youth with Autism Spectrum Disorders. Journal of Autism & Developmental Disorders. 2013;43(10):2376–92 17p. doi: 10.1007/s10803-013-1786-y. Language: English. Entry Date: 20130921. Revision Date: 20150711. Publication Type: Journal Article. X-1, X-223417283
1728 Grow L, LeBlanc L. Teaching receptive language skills: recommendations for instructors. Behav Anal Pract. 2013 Spring;6(1):56–75. X-125729507
1729 Gupta N, Saxena RK, Juneja R, . Effectiveness of Homeopathy in Four Autism Spectrum Disorder Cases. Homoeopathic Links. 2013 Winter2013;26(4):256–61 6p. Language: English. Entry Date: 20131213. Revision Date: 20150711. Publication Type: Journal Article. X-1, X-2, X-3, X-4
1730 Haddad J. Social skills for teenagers with developmental and autism spectrum disorders: The PEERS treatment manual. J Child Adolesc Ment Health. 2013;25(1):93–4. doi: 10.2989/17280583.2013.802447. X-125860311
1731 Haines C. SILENTLY SEIZING. Exceptional Parent. 2013;43(3):52–5 4p. Language: English. Entry Date: 20130723. Revision Date: 20150711. Publication Type: Journal Article. X-1, X-2
1732 Hall R. ACCOMMODATING. Exceptional Parent. 2013;43(11):49–51 3p. Language: English. Entry Date: 20140530. Revision Date: 20150710. Publication Type: Journal Article. X-1
1733 Hamade A, Salameh P, Medlej-Hashim M, . Autism in children and correlates in Lebanon: a pilot case-control study. J Res Health Sci. 2013 Summer-Autumn;13(2):119–24. X-124077467
1734 Hamlin JC, Pauly M, Melnyk S, . Dietary intake and plasma levels of choline and betaine in children with autism spectrum disorders. Autism Res Treat. 2013;2013:578429. doi: 10.1155/2013/578429. X-124396597
1735 Handen BL, Johnson CR, Butter EM, . Use of a Direct Observational Measure in a Trial of Risperidone and Parent Training in Children with Pervasive Developmental Disorders. J Dev Phys Disabil. 2013 Jun 1;25(3):355–71. doi: 10.1007/s10882-012-9316-y. X-123730123
1736 Hansel K. Rethinking insurance coverage of “experimental” Applied Behavioral Analysis therapy and its usefulness in combating autism spectrum disorder. J Leg Med. 2013;34(2):215–33. doi: 10.1080/01947648.2013.800798. X-123980747
1737 Hardy MW, Lagasse AB. Rhythm, movement, and autism: using rhythmic rehabilitation research as a model for autism. Front Integr Neurosci. 2013;7:19. doi: 10.3389/fnint.2013.00019. X-1, X-223543915
1738 Harfterkamp M, Buitelaar JK, Minderaa RB, . Long-term treatment with atomoxetine for attention-deficit/hyperactivity disorder symptoms in children and adolescents with autism spectrum disorder: an open-label extension study. J Child Adolesc Psychopharmacol. 2013 Apr;23(3):194–9. doi: 10.1089/cap.2012.0012.23578015
1739 Harper A, Taylor Dyches T, Harper J, . Respite care, marital quality, and stress in parents of children with autism spectrum disorders. J Autism Dev Disord. 2013 Nov;43(11):2604–16. doi: 10.1007/s10803-013-1812-0. X-123529841
1740 Harstad E, Huntington N, Bacic J, . Disparity of care for children with parent-reported autism spectrum disorders. Acad Pediatr. 2013 Jul–Aug;13(4):334–9. doi: 10.1016/j.acap.2013.03.010. X-123830019
1741 Hasegawa N, Yamamoto Y. [Autism spectrum disorders in elderly]. Nihon Rinsho. 2013 Oct;71(10):1847–52. X-124261218
1742 Hassanpour S, O’Connor MJ, Das AK. A semantic-based method for extracting concept definitions from scientific publications: evaluation in the autism phenotype domain. J Biomed Semantics. 2013;4(1):14. doi: 10.1186/2041-1480-4-14. X-123937724
1743 Hazen EP, McDougle CJ, Volkmar FR. Changes in the diagnostic criteria for autism in DSM-5: controversies and concerns. J Clin Psychiatry. 2013 Jul;74(7):739–40. doi: 10.4088/JCP.13ac08550. X-123945452
1744 Hellinckx T, Roeyers H, Van Waelvelde H. Predictors of handwriting in children with autism spectrum disorder. Research in Autism Spectrum Disorders. 2013 2015-12-09;7(1):176–86. doi: 10.5014/ajot.57.5.550 http://dx.doi.org/10.1016/j.rasd.2012.08.009; 2012-29769-020. X-1
1745 Hetzroni OE, Ne’eman A. Influence of colour on acquisition and generalisation of graphic symbols. J Intellect Disabil Res. 2013 Jul;57(7):669–80. doi: 10.1111/j.1365-2788.2012.01584.x. X-3, X-422676327
1746 Hildebrandt H, Fink F, Kastrup A, . Cognitive profiles of patients with mild cognitive impairment or dementia in Alzheimer’s or Parkinson’s disease. Dement Geriatr Cogn Dis Extra. 2013 Jan;3(1):102–12. doi: 10.1159/000348350. X-123637703
1747 Hill-Yardin EL, Hannan AJ. Translating preclinical environmental enrichment studies for the treatment of autism and other brain disorders: Comment on Woo and Leon (2013). Behavioral Neuroscience. 2013 2015-12-09;127(4):606–9. doi: http://dx.doi.org/10.1037/a0033319; 2013-26343-005. X-123895065
1748 Himuro N, Kozuka N, Mori M. Measurement of family-centred care: translation, adaptation and validation of the Measure of Processes of Care (MPOC-56 and -20) for use in Japan. Child Care Health Dev. 2013 May;39(3):358–65. doi: 10.1111/j.1365-2214.2012.01371.x. X-122372945
1749 Hinckson EA, Dickinson A, Water T, . Physical activity, dietary habits and overall health in overweight and obese children and youth with intellectual disability or autism. Res Dev Disabil. 2013 Apr;34(4):1170–8. doi: 10.1016/j.ridd.2012.12.006. X-123400004
1750 Hinton R, Budimirovic DB, Marschik PB, . Parental reports on early language and motor milestones in fragile X syndrome with and without autism spectrum disorders. Dev Neurorehabil. 2013;16(1):58–66. doi: 10.3109/17518423.2012.704414. X-123249372
1751 Hirata S, Okuzumi H, Kitajima Y, . Speed and accuracy of motor and cognitive control in children with intellectual disabilities. International Journal of Developmental Disabilities. 2013;59(3):166–78 13p. doi: 10.1179/2047387712Y.0000000010. Language: English. Entry Date: 20131025. Revision Date: 20150711. Publication Type: Journal Article. X-1
1752 Hodgetts S, Nicholas D, Zwaigenbaum L, . Parents’ and professionals’ perceptions of family-centered care for children with autism spectrum disorder across service sectors. Soc Sci Med. 2013 Nov;96:138–46. doi: 10.1016/j.socscimed.2013.07.012. X-124034961
1753 Hodgetts S, Savage A, McConnell D. Experience and outcomes of stepping stones triple P for families of children with autism. Res Dev Disabil. 2013 Sep;34(9):2572–85. doi: 10.1016/j.ridd.2013.05.005. X-3, X-423747943
1754 Holwerda A, van der Klink JJ, de Boer MR, . Predictors of sustainable work participation of young adults with developmental disorders. Res Dev Disabil. 2013 Sep;34(9):2753–63. doi: 10.1016/j.ridd.2013.05.032. X-123792372
1755 Hong DS. Child and adolescent psychiatrists are often tasked with the challenge of treating patients in various contexts. J Am Acad Child Adolesc Psychiatry. 2013 Sep;52(9):885–6. doi: 10.1016/j.jaac.2013.06.014. X-123972687
1756 Hosenbocus S, Chahal R. Amantadine: a review of use in child and adolescent psychiatry. J Can Acad Child Adolesc Psychiatry. 2013 Feb;22(1):55–60. X-2, X-323390434
1757 Hosenbocus S, Chahal R. Memantine: a review of possible uses in child and adolescent psychiatry. J Can Acad Child Adolesc Psychiatry. 2013 May;22(2):166–71. X-2, X-323667364
1758 Houghton K, Schuchard J, Lewis C, . Promoting child-initiated social-communication in children with autism: Son-Rise Program intervention effects. J Commun Disord. 2013 Sep–Dec;46(5–6):495–506. doi: 10.1016/j.jcomdis.2013.09.004. X-3, X-424209427
1759 Hsieh DT, Jennesson MM, Thiele EA. Epileptic spasms in tuberous sclerosis complex. Epilepsy Res. 2013 Sep;106(1–2):200–10. doi: 10.1016/j.eplepsyres.2013.05.003. X-123796861
1760 Hsieh YL, Lo JL. Occupational experiences and subjective well-being of mothers of children with ASD in Taiwan. Occup Ther Int. 2013 Mar;20(1):45–53. doi: 10.1002/oti.1339. X-123147991
1761 Hua X, Thompson PM, Leow AD, . Brain growth rate abnormalities visualized in adolescents with autism. Hum Brain Mapp. 2013 Feb;34(2):425–36. doi: 10.1002/hbm.21441. X-122021093
1762 Huang A, Seshadri K, Matthews TA, . Parental perspectives on use, benefits, and physician knowledge of complementary and alternative medicine in children with autistic disorder and attention-deficit/hyperactivity disorder. J Altern Complement Med. 2013 Sep;19(9):746–50. doi: 10.1089/acm.2012.0640. X-1, X-323621389
1763 Hurt AA, Grist CL, Malesky LA, Jr., . Personality traits associated with occupational ‘burnout’ in ABA therapists. J Appl Res Intellect Disabil. 2013 Jul;26(4):299–308. doi: 10.1111/jar.12043. X-123505135
1764 Huskens B, Verschuur R, Gillesen J, . Promoting question-asking in school-aged children with autism spectrum disorders: effectiveness of a robot intervention compared to a human-trainer intervention. Dev Neurorehabil. 2013 Oct;16(5):345–56. doi: 10.3109/17518423.2012.739212. x-423586852
1765 Ichikawa K, Takahashi Y, Ando M, . TEACCH-based group social skills training for children with high-functioning autism: a pilot randomized controlled trial. Biopsychosoc Med. 2013;7(1):14. doi: 10.1186/1751-0759-7-14. X-424083413
1766 Imbrici P, Camerino DC, Tricarico D. Major channels involved in neuropsychiatric disorders and therapeutic perspectives. Front Genet. 2013;4:76. doi: 10.3389/fgene.2013.00076. X-123675382
1767 Ingersoll B, Wainer A. Initial efficacy of project ImPACT: a parent-mediated social communication intervention for young children with ASD. J Autism Dev Disord. 2013 Dec;43(12):2943–52. doi: 10.1007/s10803-013-1840-9. X-3, X-423689760
1768 Ingersoll BR, Wainer AL. Pilot study of a school-based parent training program for preschoolers with ASD. Autism. 2013 Jul;17(4):434–48. doi: 10.1177/1362361311427155. X-322087044
1769 Ishitobi M, Kosaka H, Takahashi T, . Effectiveness and tolerability of switching to aripiprazole from risperidone in subjects with autism spectrum disorders: a prospective open-label study. Clin Neuropharmacol. 2013 Sep–Oct;36(5):151–6. doi: 10.1097/WNF.0b013e3182a31ec0. X-1, X-3, X-424045605
1770 Jackson BL, Blackwood EM, Blum J, . Magno- and Parvocellular Contrast Responses in Varying Degrees of Autistic Trait. PLoS One. 2013;8(6):e66797. doi: 10.1371/journal.pone.0066797. X-123824955
1771 Jain R, Juneja M, Sairam S. Children with developmental disabilities in India: age of initial concern and referral for rehabilitation services, and reasons for delay in referral. J Child Neurol. 2013 Apr;28(4):455–60. doi: 10.1177/0883073812447685. X-122752480
1772 Jeans LM, Santos RM, Laxman DJ, . Early Predictors of ASD in Young Children Using a Nationally Representative Data Set. Journal of Early Intervention. 2013;35(4):303–31 29p. doi: 10.1177/1053815114523319. Language: English. Entry Date: 20140923. Revision Date: 20150818. Publication Type: Journal Article. X-1
1773 Jerrell JM, Hrisko S. Utility of Two PANSS 5-Factor Models for Assessing Psychosocial Outcomes in Clinical Programs for Persons with Schizophrenia. Schizophr Res Treatment. 2013;2013:705631. doi: 10.1155/2013/705631. X-124381761
1774 Johnson CR, Turner KS, Foldes E, . Behavioral parent training to address sleep disturbances in young children with autism spectrum disorder: a pilot trial. Sleep Med. 2013 Oct;14(10):995–1004. doi: 10.1016/j.sleep.2013.05.013. X-123993773
1775 Johnson NL, Simpson PM. Lack of father involvement in research on children with autism spectrum disorder: maternal parenting stress and family functioning. Issues Ment Health Nurs. 2013 Apr;34(4):220–8. doi: 10.3109/01612840.2012.745177. X-123566184
1776 Jones RM, Cadby G, Melton PE, . Genome-wide association study of autistic-like traits in a general population study of young adults. Front Hum Neurosci. 2013;7:658. doi: 10.3389/fnhum.2013.00658. X-124133439
1777 Jordan K, King M, Hellersteth S, . Feasibility of using a humanoid robot for enhancing attention and social skills in adolescents with autism spectrum disorder. Int J Rehabil Res. 2013 Sep;36(3):221–7. doi: 10.1097/MRR.0b013e32835d0b43. X-123328816
1778 Joshi G, Wozniak J, Petty C, . Psychiatric comorbidity and functioning in a clinically referred population of adults with autism spectrum disorders: a comparative study. J Autism Dev Disord. 2013 Jun;43(6):1314–25. doi: 10.1007/s10803-012-1679-5. X-123076506
1779 Jung NH, Janzarik WG, Delvendahl I, . Impaired induction of long-term potentiation-like plasticity in patients with high-functioning autism and Asperger syndrome. Dev Med Child Neurol. 2013 Jan;55(1):83–9. doi: 10.1111/dmcn.12012. X-123157428
1780 Justice MJ, Buchovecky CM, Kyle SM, . A role for metabolism in Rett syndrome pathogenesis: New clinical findings and potential treatment targets. Rare Dis. 2013;1:e27265. doi: 10.4161/rdis.27265. X-125003017
1781 Kadam SD, French BM, Kim ST, . Altered postnatal cell proliferation in brains of mouse pups prenatally exposed to IgG from mothers of children with autistic disorder. J Exp Neurosci. 2013;7:93–9. doi: 10.4137/jen.s12979. X-125157212
1782 Kaf WA, Danesh AA. Distortion-product otoacoustic emissions and contralateral suppression findings in children with Asperger’s Syndrome. Int J Pediatr Otorhinolaryngol. 2013 Jun;77(6):947–54. doi: 10.1016/j.ijporl.2013.03.014. X-123562236
1783 Kaiser AP, Roberts MY. Parent-implemented enhanced milieu teaching with preschool children who have intellectual disabilities. J Speech Lang Hear Res. 2013 Feb;56(1):295–309. doi: 10.1044/1092-4388(2012/11-0231). X-122744141
1784 Kandalaft MR, Didehbani N, Krawczyk DC, . Virtual reality social cognition training for young adults with high-functioning autism. J Autism Dev Disord. 2013 Jan;43(1):34–44. doi: 10.1007/s10803-012-1544-6. X-122570145
1785 Kang S, O’Reilly M, Rojeski L, . Effects of tangible and social reinforcers on skill acquisition, stereotyped behavior, and task engagement in three children with autism spectrum disorders. Res Dev Disabil. 2013 Feb;34(2):739–44. doi: 10.1016/j.ridd.2012.10.007. X-1, X-423220050
1786 Karanth P, Chandhok TS. Impact of early intervention on children with autism spectrum disorders as measured by inclusion and retention in mainstream schools. Indian J Pediatr. 2013 Nov;80(11):911–9. doi: 10.1007/s12098-013-1014-y. X-123686797
1787 Karlinsky H. The Horse Boy--attending to the stories our patients tell us. Acad Psychiatry. 2013 Jul 1;37(4):271–5. doi: 10.1176/appi.ap.13040048. X-123820912
1788 Kasari C, Smith T. Interventions in schools for children with autism spectrum disorder: methods and recommendations. Autism. 2013 May;17(3):254–67. doi: 10.1177/1362361312470496. X-123592848
1789 Kato K, Mikami K, Akama F, . Clinical features of suicide attempts in adults with autism spectrum disorders. Gen Hosp Psychiatry. 2013 Jan–Feb;35(1):50–3. doi: 10.1016/j.genhosppsych.2012.09.006. X-123141028
1790 Kats D, Payne L, Parlier M, . Prevalence of selected clinical problems in older adults with autism and intellectual disability. J Neurodev Disord. 2013;5(1):27. doi: 10.1186/1866-1955-5-27. X-124066979
1791 Keehn B, Wagner JB, Tager-Flusberg H, . Functional connectivity in the first year of life in infants at-risk for autism: a preliminary near-infrared spectroscopy study. Front Hum Neurosci. 2013;7:444. doi: 10.3389/fnhum.2013.00444. X-123964223
1792 Kelly A, Barnes-Holmes D. Implicit attitudes towards children with autism versus normally developing children as predictors of professional burnout and psychopathology. Res Dev Disabil. 2013 Jan;34(1):17–28. doi: 10.1016/j.ridd.2012.07.018. X-122940155
1793 Kent JM, Hough D, Singh J, . An open-label extension study of the safety and efficacy of risperidone in children and adolescents with autistic disorder. J Child Adolesc Psychopharmacol. 2013 Dec;23(10):676–86. doi: 10.1089/cap.2012.0058.24350813
1794 Kent JM, Kushner S, Ning X, . Risperidone dosing in children and adolescents with autistic disorder: a double-blind, placebo-controlled study. J Autism Dev Disord. 2013 Aug;43(8):1773–83. doi: 10.1007/s10803-012-1723-5.23212807
1795 Kenzer AL, Bishop MR, Wilke AE, . Including unfamiliar stimuli in preference assessments for young children with autism. J Appl Behav Anal. 2013 Fall;46(3):689–94. doi: 10.1002/jaba.56. X-1, X-3, X-424114234
1796 Kern JK, Garver CR, Mehta JA, . Prospective, blinded exploratory evaluation of the PlayWisely program in children with autism spectrum disorder. Yale J Biol Med. 2013 Jun;86(2):157–67. X-3, X-423766737
1797 Kern P, Rivera NR, Chandler A, . Music therapy services for individuals with autism spectrum disorder: a survey of clinical practices and training needs. J Music Ther. 2013 Winter;50(4):274–303. doi: 10.1093/jmt/50.4.274. X-125014668
1798 Kerr TM, Muller CL, Miah M, . Genetic background modulates phenotypes of serotonin transporter Ala56 knock-in mice. Mol Autism. 2013;4(1):35. doi: 10.1186/2040-2392-4-35. X-124083388
1799 Key AP, Jones D, Dykens EM. Social and emotional processing in Prader-Willi syndrome: genetic subtype differences. J Neurodev Disord. 2013;5(1):7. doi: 10.1186/1866-1955-5-7. X-123536992
1800 Khanna R, Jariwala K, Bentley JP. Health utility assessment using EQ-5D among caregivers of children with autism. Value Health. 2013 Jul–Aug;16(5):778–88. doi: 10.1016/j.jval.2013.04.007. X-123947971
1801 Khanna R, Jariwala K, West-Strum D. Use and cost of psychotropic drugs among recipients with autism in a state Medicaid fee-for-service programme. J Intellect Disabil Res. 2013 Feb;57(2):161–71. doi: 10.1111/j.1365-2788.2012.01563.x. X-122471524
1802 Khorrami A, Tehrani-Doost M, Esteky H. Comparison between Face and Object Processing in Youths with Autism Spectrum Disorder: An event related potentials study. Iran J Psychiatry. 2013 Oct;8(4):179–87. X-125628712
1803 Kim JW, Choi CS, Kim KC, . Gastrointestinal tract abnormalities induced by prenatal valproic Acid exposure in rat offspring. Toxicol Res. 2013 Sep;29(3):173–9. doi: 10.5487/tr.2013.29.3.173. X-124386517
1804 Kim P, Park JH, Kwon KJ, . Effects of Korean red ginseng extracts on neural tube defects and impairment of social interaction induced by prenatal exposure to valproic acid. Food Chem Toxicol. 2013 Jan;51:288–96. doi: 10.1016/j.fct.2012.10.011. X-123104247
1805 King BH, Dukes K, Donnelly CL, . Baseline factors predicting placebo response to treatment in children and adolescents with autism spectrum disorders: a multisite randomized clinical trial. JAMA Pediatr. 2013 Nov;167(11):1045–52. doi: 10.1001/jamapediatrics.2013.2698.24061784
1806 King D, Dockrell JE, Stuart M. Event narratives in 11–14 year olds with autistic spectrum disorder. Int J Lang Commun Disord. 2013 Sep–Oct;48(5):522–33. doi: 10.1111/1460-6984.12025. X-124033651
1807 Klaiman C, Huffman L, Masaki L, . Tetrahydrobiopterin as a treatment for autism spectrum disorders: a double-blind, placebo-controlled trial. J Child Adolesc Psychopharmacol. 2013 Jun;23(5):320–8. doi: 10.1089/cap.2012.0127.23782126
1808 Kliemann D, Rosenblau G, Bolte S, . Face puzzle-two new video-based tasks for measuring explicit and implicit aspects of facial emotion recognition. Front Psychol. 2013;4:376. doi: 10.3389/fpsyg.2013.00376. X-123805122
1809 Kodak T, Fisher WW, Paden A, . Evaluation of the utility of a discrete-trial functional analysis in early intervention classrooms. J Appl Behav Anal. 2013 Spring;46(1):301–6. doi: 10.1002/jaba.2. X-124114103
1810 Koehler-Platten K, Grow LL, Schulze KA, . Using a lag reinforcement schedule to increase phonemic variability in children with autism spectrum disorders. Anal Verbal Behav. 2013;29(1):71–83. X-1, X-3, X-423814368
1811 Koldewyn K, Jiang Y, Weigelt S, . Global/Local Processing in Autism: Not a Disability, but a Disinclination. Journal of Autism & Developmental Disorders. 2013;43(10):2329–40 12p. doi: 10.1007/s10803-013-1777-z. Language: English. Entry Date: 20130921. Revision Date: 20150711. Publication Type: Journal Article. X-123378063
1812 Kouijzer ME, van Schie HT, Gerrits BJ, . Is EEG-biofeedback an effective treatment in autism spectrum disorders? A randomized controlled trial. Appl Psychophysiol Biofeedback. 2013 Mar;38(1):17–28. doi: 10.1007/s10484-012-9204-3. X-122903518
1813 Krieger AE, Saias T, Adrien JL. [Promoting family-professional partnership in institutions for children with autism]. Encephale. 2013 Apr;39(2):130–6. doi: 10.1016/j.encep.2012.06.002. X-123095583
1814 Kryzak LA, Bauer S, Jones EA, . Increasing responding to others’ joint attention directives using circumscribed interests. J Appl Behav Anal. 2013 Fall;46(3):674–9. doi: 10.1002/jaba.73. X-3, X-424114231
1815 Kuroda M, Kawakubo Y, Kuwabara H, . A cognitive-behavioral intervention for emotion regulation in adults with high-functioning autism spectrum disorders: study protocol for a randomized controlled trial. Trials. 2013;14:231. doi: 10.1186/1745-6215-14-231. X-123880333
1816 Kutchko KM, Frohlich F. Emergence of metastable state dynamics in interconnected cortical networks with propagation delays. PLoS Comput Biol. 2013 Oct;9(10):e1003304. doi: 10.1371/journal.pcbi.1003304. X-124204238
1817 Lahav O, Apter A, Ratzon NZ. Psychological adjustment and levels of self esteem in children with visual-motor integration difficulties influences the results of a randomized intervention trial. Res Dev Disabil. 2013 Jan;34(1):56–64. doi: 10.1016/j.ridd.2012.07.024. X-122940159
1818 Lahiri U, Bekele E, Dohrmann E, . Design of a virtual reality based adaptive response technology for children with autism. IEEE Trans Neural Syst Rehabil Eng. 2013 Jan;21(1):55–64. doi: 10.1109/tnsre.2012.2218618. X-123033333
1819 Lakhan R. The coexistence of psychiatric disorders and intellectual disability in children aged 3–18 years in the barwani district, India. ISRN Psychiatry. 2013;2013:875873. doi: 10.1155/2013/875873. X-123738223
1820 Landry O, Parker A. A meta-analysis of visual orienting in autism. Front Hum Neurosci. 2013;7:833. doi: 10.3389/fnhum.2013.00833. X-124367314
1821 Landy SH, Kaniecki RG, Taylor FR. Abstracts and Citations. Headache: The Journal of Head & Face Pain. 2013;53(9):1504–14 11p. doi: 10.1111/head.12219. Language: English. Entry Date: 20131008. Revision Date: 20150711. Publication Type: Journal Article. X-1
1822 Lane AE, Heathcock JC. Early Sensory-Motor Signs of Autism Spectrum Disorder: Implications for Clinical Practice. Developmental Disabilities Special Interest Section Quarterly. 2013;37(3):1–4 p. Language: English. Entry Date: 20140926. Revision Date: 20150820. Publication Type: Journal Article. Journal Subset: Allied Health. X-1
1823 Lang R, Davenport K, Britt C, . Functional analysis and treatment of diurnal bruxism. J Appl Behav Anal. 2013 Spring;46(1):322–7. doi: 10.1002/jaba.5. X-3, X-424114107
1824 Langdon PE, Murphy GH, Clare IC, . An evaluation of the EQUIP treatment programme with men who have intellectual or other developmental disabilities. J Appl Res Intellect Disabil. 2013 Mar;26(2):167–80. doi: 10.1111/jar.12004. X-123281218
1825 Langdon PE, Murphy GH, Wilson E, . Asperger syndrome and anxiety disorders (PAsSA) treatment trial: a study protocol of a pilot, multicentre, single-blind, randomised crossover trial of group cognitive behavioural therapy. BMJ Open. 2013;3(7) doi: 10.1136/bmjopen-2013-003449. X-1, X-2, X-3
1826 Lange N, McDougle C. Help for the child with autism. Sci Am. 2013 Oct;309(4):72–7. X-1, X-2
1827 Langone SR, Luiselli JK, Hamill J. Effects of Response Blocking and Programmed Stimulus Control on Motor Stereotypy: A Pilot Study. Child & Family Behavior Therapy. 2013;35(3):249–55 7p. doi: 10.1080/07317107.2013.818906. Language: English. Entry Date: 20130920. Revision Date: 20150711. Publication Type: Journal Article. X-1, X-3, X-4
1828 Lanz TA, Guilmette E, Gosink MM, . Transcriptomic analysis of genetically defined autism candidate genes reveals common mechanisms of action. Mol Autism. 2013;4(1):45. doi: 10.1186/2040-2392-4-45. X-124238429
1829 Lau NM, Green PH, Taylor AK, . Markers of Celiac Disease and Gluten Sensitivity in Children with Autism. PLoS One. 2013;8(6):e66155. doi: 10.1371/journal.pone.0066155. X-123823064
1830 Lehti V, Brown AS, Gissler M, . Autism spectrum disorders in IVF children: a national case-control study in Finland. Hum Reprod. 2013 Mar;28(3):812–8. doi: 10.1093/humrep/des430. X-123293220
1831 Lepper TL, Petursdottir AI, Esch BE. Effects of operant discrimination training on the vocalizations of nonverbal children with autism. J Appl Behav Anal. 2013 Fall;46(3):656–61. doi: 10.1002/jaba.55. X-3, X-424114228
1832 Levin-Decanini T, Maltman N, Francis SM, . Parental broader autism subphenotypes in ASD affected families: relationship to gender, child’s symptoms, SSRI treatment, and platelet serotonin. Autism Res. 2013 Dec;6(6):621–30. doi: 10.1002/aur.1322. X-123956104
1833 Lipina TV, Roder JC. Co-learning facilitates memory in mice: a new avenue in social neuroscience. Neuropharmacology. 2013 Jan;64:283–93. doi: 10.1016/j.neuropharm.2012.06.054. X-122776545
1834 Lippman-Bell JJ, Rakhade SN, Klein PM, . AMPA receptor antagonist NBQX attenuates later-life epileptic seizures and autistic-like social deficits following neonatal seizures. Epilepsia. 2013 Nov;54(11):1922–32. doi: 10.1111/epi.12378. X-124117347
1835 Liu KP, Wong D, Chung AC, . Effectiveness of a workplace training programme in improving social, communication and emotional skills for adults with autism and intellectual disability in Hong Kong--a pilot study. Occup Ther Int. 2013 Dec;20(4):198–204. doi: 10.1002/oti.1356. X-123861094
1836 Liu WP, Wang J, Qu SQ, . [Transplantation of human neural precursor cells in the treatment of children with pervasive developmental disorder]. Zhongguo Dang Dai Er Ke Za Zhi. 2013 Oct;15(10):860–5. X-1, X-3, X-424131839
1837 Liyanage VR, Zachariah RM, Rastegar M. Decitabine alters the expression of Mecp2 isoforms via dynamic DNA methylation at the Mecp2 regulatory elements in neural stem cells. Mol Autism. 2013;4(1):46. doi: 10.1186/2040-2392-4-46. X-124238559
1838 Lloyd M, MacDonald M, Lord C. Motor skills of toddlers with autism spectrum disorders. Autism: The International Journal of Research & Practice. 2013;17(2):133–46 14p. doi: 10.1177/1362361311402230. Language: English. Entry Date: 20130321. Revision Date: 20150711. Publication Type: Journal Article. X-121610184
1839 Lloyd-Fox S, Blasi A, Elwell CE, . Reduced neural sensitivity to social stimuli in infants at risk for autism. Proc Biol Sci. 2013 May 7;280(1758):20123026. doi: 10.1098/rspb.2012.3026. X-123486434
1840 Lopata C, Smith RA, Volker MA, . Comparison of Adaptive Behavior Measures for Children with HFASDs. Autism Res Treat. 2013;2013:415989. doi: 10.1155/2013/415989. X-123819048
1841 Lopata C, Toomey JA, Fox JD, . Prevalence and Predictors of Psychotropic Use in Children with High-Functioning ASDs. Autism Res Treat. 2013;2013:384527. doi: 10.1155/2013/384527. X-123762550
1842 Lord C, Jones RM. New strategies and findings for behavioral interventions in autism spectrum disorders. Ann N Y Acad Sci. 2013 Nov;1304:70–6. doi: 10.1111/nyas.12311. X-124279894
1843 Louw KA, Bentley J, Sorsdahl K, . Prevalence and patterns of medication use in children and adolescents with autism spectrum disorders in the Western Cape, South Africa. J Child Adolesc Ment Health. 2013;25(1):69–79. doi: 10.2989/17280583.2013.767265. X-125860309
1844 Lv YT, Zhang Y, Liu M, . Transplantation of human cord blood mononuclear cells and umbilical cord-derived mesenchymal stem cells in autism. J Transl Med. 2013;11:196. doi: 10.1186/1479-5876-11-196.23978163
1845 Lyalina S, Percha B, Lependu P, . Identifying phenotypic signatures of neuropsychiatric disorders from electronic medical records. Journal of the American Medical Informatics Association. 2013;20(e2):e297–305 1p. doi: 10.1136/amiajnl-2013-001933. Language: English. Entry Date: 20140207. Revision Date: 20150710. Publication Type: Journal Article. X-123956017
1846 Lyall K, Munger KL, O’Reilly EJ, . Maternal dietary fat intake in association with autism spectrum disorders. Am J Epidemiol. 2013 Jul 15;178(2):209–20. doi: 10.1093/aje/kws433. X-123813699
1847 Ma WJ, Hashii M, Munesue T, . Non-synonymous single-nucleotide variations of the human oxytocin receptor gene and autism spectrum disorders: a case-control study in a Japanese population and functional analysis. Mol Autism. 2013;4(1):22. doi: 10.1186/2040-2392-4-22. X-123815867
1848 MacDonald JM, Ahearn WH, Parry-Cruwys D, . Persistence during extinction: examining the effects of continuous and intermittent reinforcement on problem behavior. J Appl Behav Anal. 2013 Spring;46(1):333–8. doi: 10.1002/jaba.3. X-3, X-424114109
1849 MacDonald M, Lord C, Ulrich D. The relationship of motor skills and adaptive behavior skills in young children with autism spectrum disorders. Res Autism Spectr Disord. 2013 Nov 1;7(11):1383–90. doi: 10.1016/j.rasd.2013.07.020. X-125774214
1850 MacDonald M, Lord C, Ulrich DA. The Relationship of Motor Skills and Social Communicative Skills in School-Aged Children With Autism Spectrum Disorder. Adapted Physical Activity Quarterly. 2013;30(3):271–82 12p. Language: English. Entry Date: 20130816. Revision Date: 20150712. Publication Type: Journal Article. X-123860508
1851 Maenner MJ, Smith LE, Hong J, . Evaluation of an activities of daily living scale for adolescents and adults with developmental disabilities. Disabil Health J. 2013 Jan;6(1):8–17. doi: 10.1016/j.dhjo.2012.08.005. X-123260606
1852 Magana S, Lopez K, Aguinaga A, . Access to diagnosis and treatment services among latino children with autism spectrum disorders. Intellect Dev Disabil. 2013 Jun;51(3):141–53. doi: 10.1352/1934-9556-51.3.141. X-123834211
1853 Malek-Ahmadi M, Kahlon V, Adler CH, . Prevalence of Hippocampal Sclerosis in a Clinicopathologically Characterized Cohort. Clin Exp Med Sci. 2013;1(7):317–27. X-125324686
1854 Mamidala MP, Polinedi A, Kumar PT, . Maternal hormonal interventions as a risk factor for Autism Spectrum Disorder: an epidemiological assessment from India. J Biosci. 2013 Dec;38(5):887–92. X-124296891
1855 Mankoski R, Stockton G, Manos G, . Aripiprazole treatment of irritability associated with autistic disorder and the relationship between prior antipsychotic exposure, adverse events, and weight change. J Child Adolesc Psychopharmacol. 2013 Oct;23(8):572–6. doi: 10.1089/cap.2012.0075. X-2, X-324138011
1856 Manoach DS, Agam Y. Neural markers of errors as endophenotypes in neuropsychiatric disorders. Front Hum Neurosci. 2013;7:350. doi: 10.3389/fnhum.2013.00350. X-123882201
1857 Mardh S. Weak central coherence in patients with Alzheimer’s disease(*). Neural Regen Res. 2013 Mar 15;8(8):760–6. doi: 10.3969/j.issn.1673-5374.2013.08.011. X-125206723
1858 Margari L, Matera E, Craig F, . Tolerability and safety profile of risperidone in a sample of children and adolescents. Int Clin Psychopharmacol. 2013 Jul;28(4):177–83. doi: 10.1097/YIC.0b013e328362497b. X-1, X-323689836
1859 Marshall J, Hill RJ, Dodrill P. A survey of practice for clinicians working with children with autism spectrum disorders and feeding difficulties. Int J Speech Lang Pathol. 2013 Jun;15(3):279–85. doi: 10.3109/17549507.2013.777972. X-123577744
1860 Martin GE, Losh M, Estigarribia B, . Longitudinal profiles of expressive vocabulary, syntax and pragmatic language in boys with fragile X syndrome or Down syndrome. Int J Lang Commun Disord. 2013 Jul–Aug;48(4):432–43. doi: 10.1111/1460-6984.12019. X-123889838
1861 Martins LZ, Fernandes FD. Short-term speech-language intervention for children with disorders of the autism spectrum. Codas. 2013;25(6):542–7. doi: 10.1590/s2317-17822014000100007. X-124626980
1862 Masri AT, Al Suluh N, Nasir R. Diagnostic delay of autism in Jordan: review of 84 cases. Libyan J Med. 2013;8:21725. doi: 10.3402/ljm.v8i0.21725. X-1
1863 Massand E, Bowler D, Mottron L, . ERP Correlates of Recognition Memory in Autism Spectrum Disorder…Event-Related Potential. Journal of Autism & Developmental Disorders. 2013;43(9):2038–47 10p. doi: 10.1007/s10803-012-1755-x. Language: English. Entry Date: 20130820. Revision Date: 20150711. Publication Type: Journal Article. X-123307419
1864 Mathersul D, McDonald S, Rushby JA. Psychophysiological correlates of social judgement in high-functioning adults with autism spectrum disorder. Int J Psychophysiol. 2013 Jan;87(1):88–94. doi: 10.1016/j.ijpsycho.2012.11.005. X-123183316
1865 Mattard-Labrecque C, Ben Amor L, Couture MM. Children with Autism and Attention Difficulties: A Pilot Study of the Association between Sensory, Motor, and Adaptive Behaviors. J Can Acad Child Adolesc Psychiatry. 2013 May;22(2):139–46. X-123667360
1866 Maxwell CR, Parish-Morris J, Hsin O, . The broad autism phenotype predicts child functioning in autism spectrum disorders. J Neurodev Disord. 2013;5(1):25. doi: 10.1186/1866-1955-5-25. X-124053506
1867 May T, Rinehart N, Wilding J, . The Role of Attention in the Academic Attainment of Children with Autism Spectrum Disorder. Journal of Autism & Developmental Disorders. 2013;43(9):2147–58 12p. doi: 10.1007/s10803-013-1766-2. Language: English. Entry Date: 20130820. Revision Date: 20150711. Publication Type: Journal Article. X-123378062
1868 Mazurek MO, Engelhardt CR. Video game use in boys with autism spectrum disorder, ADHD, or typical development. Pediatrics. 2013 Aug;132(2):260–6. doi: 10.1542/peds.2012-3956. X-123897915
1869 McCabe H. Bamboo shoots after the rain: development and challenges of autism intervention in China. Autism. 2013 Sep;17(5):510–26. doi: 10.1177/1362361312436849. X-123144167
1870 McCartney M. MMR, measles, and the South Wales Evening Post. Bmj. 2013;346:f2598. doi: 10.1136/bmj.f2598. X-123610382
1871 McCary LM, Machlin L, Roberts JE. The Development of Adaptive Behavior in Toddlers and Preschoolers with Fragile X versus Autism. Int J Dev Disabil. 2013 Jul 1;59(2):67–79. doi: 10.1179/2047387713y.0000000016. X-125191537
1872 McCary LM, Machlin L, Roberts JE. The development of adaptive behaviour in toddlers and preschoolers with fragile X versus autism. International Journal of Developmental Disabilities. 2013;59(2):67–79 13p. doi: 10.1179/2047387713Y.0000000016. Language: English. Entry Date: 20130606. Revision Date: 20150711. Publication Type: Journal Article. X-125191537
1873 McCleery JP, Elliott NA, Sampanis DS, . Motor development and motor resonance difficulties in autism: relevance to early intervention for language and communication skills. Front Integr Neurosci. 2013;7:30. doi: 10.3389/fnint.2013.00030. X-1, X-223630476
1874 McGhan AC, Lerman DC. An assessment of error-correction procedures for learners with autism. J Appl Behav Anal. 2013 Fall;46(3):626–39. doi: 10.1002/jaba.65. X-1, X-3, X-424114225
1875 McGonigle-Chalmers M, Alderson-Day B, Fleming J, . Profound Expressive Language Impairment in Low Functioning Children with Autism: An Investigation of Syntactic Awareness Using a Computerised Learning Task. Journal of Autism & Developmental Disorders. 2013;43(9):2062–81 20p. doi: 10.1007/s10803-012-1753-z. Language: English. Entry Date: 20130820. Revision Date: 20150711. Publication Type: Journal Article. X-123292162
1876 McGregor KK, Rost G, Arenas R, . Children with ASD can use gaze in support of word recognition and learning. J Child Psychol Psychiatry. 2013 Jul;54(7):745–53. doi: 10.1111/jcpp.12073. X-123574387
1877 McGuinness TM, Johnson K. DSM-5 changes in the diagnosis of autism spectrum disorder. J Psychosoc Nurs Ment Health Serv. 2013 Apr;51(4):17–9. doi: 10.3928/02793695-20130220-01. X-1
1878 McIntosh CE. A national survey exploring school nurses knowledge and experience when working with children with Autism Spectrum Disorders: Ball State University; 2013.
1879 McMahon CM, Lerner MD, Britton N. Group-based social skills interventions for adolescents with higher-functioning autism spectrum disorder: a review and looking to the future. Adolesc Health Med Ther. 2013 Jan 22;2013(4):23–8. doi: 10.2147/ahmt.s25402. X-1, X-223956616
1880 McMahon CM, Vismara LA, Solomon M. Measuring changes in social behavior during a social skills intervention for higher-functioning children and adolescents with autism spectrum disorder. J Autism Dev Disord. 2013 Aug;43(8):1843–56. doi: 10.1007/s10803-012-1733-3. X-123239098
1881 McNally Keehn RH, Lincoln AJ, Brown MZ, . The Coping Cat program for children with anxiety and autism spectrum disorder: a pilot randomized controlled trial. J Autism Dev Disord. 2013 Jan;43(1):57–67. doi: 10.1007/s10803-012-1541-9. X-122588377
1882 Meador KJ, Loring DW. Prenatal valproate exposure is associated with autism spectrum disorder and childhood autism. Journal of Pediatrics. 2013;163(3):922–6 5p. doi: 10.1016/j.jpeds.2013.06.050. Language: English. Entry Date: 20131129. Revision Date: 20150711. Publication Type: Journal Article. X-123973242
1883 Meador KJ, Loring DW. Risks of in utero exposure to valproate. JAMA: Journal of the American Medical Association. 2013;309(16):1730–1 2p. doi: 10.1001/jama.2013.4001. Language: English. Entry Date: 20130510. Revision Date: 20150712. Publication Type: Journal Article. X-123613078
1884 Memari AH, Ghaheri B, Ziaee V, . Physical activity in children and adolescents with autism assessed by triaxial accelerometry. Pediatr Obes. 2013 Apr;8(2):150–8. doi: 10.1111/j.2047-6310.2012.00101.x. X-123042790
1885 Memari AH, Shayestehfar M, Mirfazeli FS, . Cross-cultural adaptation, reliability, and validity of the autism treatment evaluation checklist in persian. Iran J Pediatr. 2013 Jun;23(3):269–75. X-123795248
1886 Memari AH, Ziaee V, Shayestehfar M, . Cognitive flexibility impairments in children with autism spectrum disorders: links to age, gender and child outcomes. Res Dev Disabil. 2013 Oct;34(10):3218–25. doi: 10.1016/j.ridd.2013.06.033. X-123886763
1887 Meola D, Huang Z, Petitto JM. Selective Neuronal and Brain Regional Expession of IL-2 in IL2P 8-GFP Transgenic Mice: Relation to Sensorimotor Gating. J Alzheimers Dis Parkinsonism. 2013 Oct 28;3(4):1000127. doi: 10.4172/2161-0460.1000127. X-124563821
1888 Mercati O, Danckaert A, Andre-Leroux G, . Contactin 4, -5 and -6 differentially regulate neuritogenesis while they display identical PTPRG binding sites. Biol Open. 2013 Mar 15;2(3):324–34. doi: 10.1242/bio.20133343. X-123519440
1889 Miguel CF, Kobari-Wright VV. The effects of tact training on the emergence of categorization and listener behavior in children with autism. J Appl Behav Anal. 2013 Fall;46(3):669–73. doi: 10.1002/jaba.62. X-3, X-424114230
1890 Miyajima T, Kumada T, Saito K, . Autism in siblings with autosomal dominant nocturnal frontal lobe epilepsy. Brain Dev. 2013 Feb;35(2):155–7. doi: 10.1016/j.braindev.2012.07.012. X-122883468
1891 Miyake K, Yang C, Minakuchi Y, . Comparison of Genomic and Epigenomic Expression in Monozygotic Twins Discordant for Rett Syndrome. PLoS One. 2013;8(6):e66729. doi: 10.1371/journal.pone.0066729. X-123805272
1892 Mohammadi MR, Yadegari N, Hassanzadeh E, . Double-blind, placebo-controlled trial of risperidone plus amantadine in children with autism: a 10-week randomized study. Clin Neuropharmacol. 2013 Nov–Dec;36(6):179–84. doi: 10.1097/WNF.0b013e3182a9339d.24201232
1893 Mohiuddin S, Ghaziuddin M. Psychopharmacology of autism spectrum disorders: A selective review. Autism: The International Journal of Research & Practice. 2013;17(6):645–54 10p. doi: 10.1177/1362361312453776. Language: English. Entry Date: 20131106. Revision Date: 20150711. Publication Type: Journal Article. X-1, X-222892891
1894 Monahan M, Classen S, Helsel PV. Pre-driving evaluation of a teen with attention deficit hyperactivity disorder and autism spectrum disorder. Can J Occup Ther. 2013 Feb;80(1):35–41. X-123550495
1895 Monsey MS. Introduction: how dysregulation of mental processes and behaviors lead to pathology. Yale J Biol Med. 2013 Jun;86(2):115–6. X-123923130
1896 Moran MF, Foley JT, Parker ME, . Two-legged hopping in autism spectrum disorders. Front Integr Neurosci. 2013;7:14. doi: 10.3389/fnint.2013.00014. X-123532337
1897 Moss J, Oliver C, Nelson L, . Delineating the profile of autism spectrum disorder characteristics in Cornelia de Lange and Fragile X syndromes. Am J Intellect Dev Disabil. 2013 Jan;118(1):55–73. doi: 10.1352/1944-7558-118.1.55. X-123301903
1898 Moy SS, Nonneman RJ, Shafer GO, . Disruption of social approach by MK-801, amphetamine, and fluoxetine in adolescent C57BL/6J mice. Neurotoxicol Teratol. 2013 Mar–Apr;36:36–46. doi: 10.1016/j.ntt.2012.07.007. X-122898204
1899 Murdock LC, Ganz J, Crittendon J. Use of an iPad play story to increase play dialogue of preschoolers with Autism Spectrum Disorders. J Autism Dev Disord. 2013 Sep;43(9):2174–89. doi: 10.1007/s10803-013-1770-6. X-3, X-423371509
1900 Muskett T, Body R. The case for multimodal analysis of atypical interaction: questions, answers and gaze in play involving a child with autism. Clin Linguist Phon. 2013 Oct–Nov;27(10–11):837–50. doi: 10.3109/02699206.2013.816780. X-124067142
1901 Naber FB, Poslawsky IE, van Ijzendoorn MH, . Brief report: oxytocin enhances paternal sensitivity to a child with autism: a double-blind within-subject experiment with intranasally administered oxytocin. J Autism Dev Disord. 2013 Jan;43(1):224–9. doi: 10.1007/s10803-012-1536-6. X-1, X-422544470
1902 Narayanan S, Georgiou PG. Behavioral Signal Processing: Deriving Human Behavioral Informatics From Speech and Language: Computational techniques are presented to analyze and model expressed and perceived human behavior-variedly characterized as typical, atypical, distressed, and disordered-from speech and language cues and their applications in health, commerce, education, and beyond. Proc IEEE Inst Electr Electron Eng. 2013 Feb 7;101(5):1203–33. doi: 10.1109/jproc.2012.2236291. X-124039277
1903 Narcisa V, Discenza M, Vaccari E, . Parental interest in a genetic risk assessment test for autism spectrum disorders. Clin Pediatr (Phila). 2013 Feb;52(2):139–46. doi: 10.1177/0009922812466583. X-123193169
1904 Naviaux RK, Zolkipli Z, Wang L, . Antipurinergic therapy corrects the autism-like features in the poly(IC) mouse model. PLoS One. 2013;8(3):e57380. doi: 10.1371/journal.pone.0057380. X-123516405
1905 Neubauer Mde A, Fernandes FD. Functional Communication Profile and speech-language diagnosis in children of the autism spectrum: checklist use. Codas. 2013;25(6):605–9. doi: 10.1590/s2317-17822014000100013. X-124626986
1906 Neufeld J, Roy M, Zapf A, . Is synesthesia more common in patients with Asperger syndrome? Front Hum Neurosci. 2013;7:847. doi: 10.3389/fnhum.2013.00847. X-124367321
1907 Nicolaidis C, Raymaker D, McDonald K, . Comparison of healthcare experiences in autistic and non-autistic adults: a cross-sectional online survey facilitated by an academic-community partnership. J Gen Intern Med. 2013 Jun;28(6):761–9. doi: 10.1007/s11606-012-2262-7. X-123179969
1908 Nosik MR, Williams WL, Garrido N, . Comparison of computer based instruction to behavior skills training for teaching staff implementation of discrete-trial instruction with an adult with autism. Res Dev Disabil. 2013 Jan;34(1):461–8. doi: 10.1016/j.ridd.2012.08.011. x-123041660
1909 Nurmi EL, Spilman SL, Whelan F, . Moderation of antipsychotic-induced weight gain by energy balance gene variants in the RUPP autism network risperidone studies. Transl Psychiatry. 2013;3:e274. doi: 10.1038/tp.2013.26. X-323799528
1910 Nylander L, Holmqvist M, Gustafson L, . Attention-deficit/hyperactivity disorder (ADHD) and autism spectrum disorder (ASD) in adult psychiatry. A 20-year register study. Nord J Psychiatry. 2013 Oct;67(5):344–50. doi: 10.3109/08039488.2012.748824. X-123234539
1911 Occelli V, Esposito G, Venuti P, . The Takete-Maluma phenomenon in autism spectrum disorders. Perception. 2013;42(2):233–41. X-123700961
1912 Odeberg H, Martensson B. [Underlying factors should be examined in prolonged sick leave for depression]. Lakartidningen. 2013 Sep 4–10;110(36):1552–3. X-124163911
1913 Oerlemans AM, Droste K, van Steijn DJ, . Co-segregation of Social Cognition, Executive Function and Local Processing Style in Children with ASD, their Siblings and Normal Controls. Journal of Autism & Developmental Disorders. 2013;43(12):2764–78 15p. doi: 10.1007/s10803-013-1807-x. Language: English. Entry Date: 20131113. Revision Date: 20150711. Publication Type: Journal Article. X-123532348
1914 Oguchi-Katayama A, Monma A, Sekino Y, . Comparative gene expression analysis of the amygdala in autistic rat models produced by pre- and post-natal exposures to valproic acid. J Toxicol Sci. 2013;38(3):391–402. X-123665938
1915 O’Hearn K, Franconeri S, Wright C, . The development of individuation in autism. J Exp Psychol Hum Percept Perform. 2013 Apr;39(2):494–509. doi: 10.1037/a0029400. X-1, X-322963232
1916 Okuno H, Nagai T, Mohri I, . [Effectiveness of a modified parent training of smaller groups and shorter schedules for children with pervasive developmental disorders]. No To Hattatsu. 2013 Jan;45(1):26–32. X-323593742
1917 Olexova L, Senko T, Stefanik P, . Habituation of exploratory behaviour in VPA rats: animal model of autism. Interdiscip Toxicol. 2013 Dec;6(4):222–7. doi: 10.2478/intox-2013-0033. X-124678262
1918 Omori M, Yamamoto J. Stimulus pairing training for Kanji reading skills in students with developmental disabilities. Res Dev Disabil. 2013 Apr;34(4):1109–18. doi: 10.1016/j.ridd.2012.12.016. X-123357673
1919 Onore CE, Careaga M, Babineau BA, . Inflammatory macrophage phenotype in BTBR T+tf/J mice. Front Neurosci. 2013;7:158. doi: 10.3389/fnins.2013.00158. X-124062633
1920 Oranje B, Lahuis B, van Engeland H, . Sensory and sensorimotor gating in children with multiple complex developmental disorders (MCDD) and autism. Psychiatry Res. 2013 Apr 30;206(2–3):287–92. doi: 10.1016/j.psychres.2012.10.014. X-123164481
1921 Owen JP, Marco EJ, Desai S, . Abnormal white matter microstructure in children with sensory processing disorders. Neuroimage Clin. 2013;2:844–53. doi: 10.1016/j.nicl.2013.06.009. X-124179836
1922 Palmer CJ, Paton B, Hohwy J, . Movement under uncertainty: The effects of the rubber-hand illusion vary along the nonclinical autism spectrum. Neuropsychologia. 2013 2015-12-09;51(10):1942–51. doi: http://dx.doi.org/10.1016/j.neuropsychologia.2013.06.020; 2013-29214-019. X-123811293
1923 Pan WD, Yoshida S, Liu Q, . Quantitative evaluation of severity of behavioral and psychological symptoms of dementia in patients with vascular dementia. Transl Neurodegener. 2013;2(1):9. doi: 10.1186/2047-9158-2-9. X-123607744
1924 Panagopoulos VN, Greene DJ, Campbell MC, . Towards objectively quantifying sensory hypersensitivity: a pilot study of the “Ariana effect”. PeerJ. 2013;1:e121. doi: 10.7717/peerj.121. X-123940834
1925 Pardo CA, Buckley A, Thurm A, . A pilot open-label trial of minocycline in patients with autism and regressive features. J Neurodev Disord. 2013;5(1):9. doi: 10.1186/1866-1955-5-9. X-323566357
1926 Parellada M, Boada L, Moreno C, . Specialty Care Programme for autism spectrum disorders in an urban population: A case-management model for health care delivery in an ASD population. Eur Psychiatry. 2013 Feb;28(2):102–9. doi: 10.1016/j.eurpsy.2011.06.004. X-121907549
1927 Parenteau RE, Luiselli JK, Keeley M. Direct and collateral effects of staff-worn protective equipment on injury prevention from child aggression. Dev Neurorehabil. 2013;16(1):73–7. doi: 10.3109/17518423.2012.700651. X-123249373
1928 Parish-Morris J, Chevallier C, Tonge N, . Visual attention to dynamic faces and objects is linked to face processing skills: a combined study of children with autism and controls. Front Psychol. 2013;4:185. doi: 10.3389/fpsyg.2013.00185. X-123596436
1929 Park DH, Lim S, Park ES, . A nine-month-old boy with isodicentric chromosome 15: a case report. Ann Rehabil Med. 2013 Apr;37(2):291–4. doi: 10.5535/arm.2013.37.2.291. X-123705128
1930 Parker W, Ollerton J. Evolutionary biology and anthropology suggest biome reconstitution as a necessary approach toward dealing with immune disorders. Evol Med Public Health. 2013 Jan;2013(1):89–103. doi: 10.1093/emph/eot008. X-124481190
1931 Pascoe JM. Foreword. Curr Probl Pediatr Adolesc Health Care. 2013 Jan;43(1):1. doi: 10.1016/j.cppeds.2012.09.001. X-123332396
1932 Pastrana SJ, Rapp JT, Frewing TM. Immediate and Subsequent Effects of Response Interruption and Redirection on Targeted and Untargeted Forms of Stereotypy. Behavior Modification. 2013;37(4):591–610 20p. doi: 10.1177/0145445513485751. Language: English. Entry Date: 20130618. Revision Date: 20150711. Publication Type: Journal Article. X-1, X-323620376
1933 Patriquin MA, Lorenzi J, Scarpa A. Relationship between respiratory sinus arrhythmia, heart period, and caregiver-reported language and cognitive delays in children with autism spectrum disorders. Appl Psychophysiol Biofeedback. 2013 Sep;38(3):203–7. doi: 10.1007/s10484-013-9225-6. X-123820819
1934 Patten E, Baranek GT, Watson LR, . Child and family characteristics influencing intervention choices in autism spectrum disorders. Focus Autism Other Dev Disabl. 2013 Sep 1;28(3):138–46. doi: 10.1177/1088357612468028. X-124089593
1935 Paul R, Campbell D, Gilbert K, . Comparing spoken language treatments for minimally verbal preschoolers with autism spectrum disorders. J Autism Dev Disord. 2013 Feb;43(2):418–31. doi: 10.1007/s10803-012-1583-z. X-122733301
1936 Pearson DA, Santos CW, Aman MG, . Effects of extended release methylphenidate treatment on ratings of attention-deficit/hyperactivity disorder (ADHD) and associated behavior in children with autism spectrum disorders and ADHD symptoms. J Child Adolesc Psychopharmacol. 2013 Jun;23(5):337–51. doi: 10.1089/cap.2012.0096.23782128
1937 Pequegnat B, Sagermann M, Valliani M, . A vaccine and diagnostic target for Clostridium bolteae, an autism-associated bacterium. Vaccine. 2013 Jun 10;31(26):2787–90. doi: 10.1016/j.vaccine.2013.04.018. X-123602537
1938 Perea RD, Rada RC, Wilson J, . A Comparative White Matter Study with Parkinson’s disease, Parkinson’s Disease with Dementia and Alzheimer’s Disease. J Alzheimers Dis Parkinsonism. 2013 Aug 26;3:123. doi: 10.4172/2161-0460.1000123. X-124724042
1939 Perez Velazquez JL, Galan RF. Information gain in the brain’s resting state: A new perspective on autism. Front Neuroinform. 2013;7:37. doi: 10.3389/fninf.2013.00037. X-124399963
1940 Perou R, Bitsko RH, Blumberg SJ, . Mental health surveillance among children--United States, 2005–2011. MMWR Surveill Summ. 2013 May 17;62(Suppl 2):1–35. X-1
1941 Perovic A, Modyanova N, Wexler K. Comparison of Grammar in Neurodevelopmental Disorders: The Case of Binding in Williams Syndrome and Autism With and Without Language Impairment. Lang Acquis. 2013 Apr;20(2):133–54. doi: 10.1080/10489223.2013.766742. X-125170241
1942 Perumal N, Balan N, Stanfield A. Psychopharmacology in children with intellectual disability and autism - a cross-sectional analysis (2010). International Journal of Developmental Disabilities. 2013;59(1):11–9 9p. doi: 10.1179/2047386912Z.00000000016. Language: English. Entry Date: 20130305. Revision Date: 20150711. Publication Type: Journal Article. X-1, X-3
1943 Peters JM, Taquet M, Prohl AK, . Diffusion tensor imaging and related techniques in tuberous sclerosis complex: review and future directions. Future Neurol. 2013 Sep;8(5):583–97. doi: 10.2217/fnl.13.37. X-124489482
1944 Peters LC, Thompson RH. Some indirect effects of positive practice overcorrection. J Appl Behav Anal. 2013 Fall;46(3):613–25. doi: 10.1002/jaba.63. X-124114224
1945 Peters-Scheffer N, Didden R, Korzilius H, . Therapist characteristics predict discrete trial teaching procedural fidelity. Intellect Dev Disabil. 2013 Aug;51(4):263–72. doi: 10.1352/1934-9556-51.4.263. X-1, X-323909620
1946 Pizzarelli R, Cherubini E. Developmental regulation of GABAergic signalling in the hippocampus of neuroligin 3 R451C knock-in mice: an animal model of Autism. Front Cell Neurosci. 2013;7:85. doi: 10.3389/fncel.2013.00085. X-123761734
1947 Plumb AM, Plexico LW. Autism spectrum disorders: experience, training, and confidence levels of school-based speech-language pathologists. Lang Speech Hear Serv Sch. 2013 Jan;44(1):89–104. doi: 10.1044/0161-1461(2012/11-0105). X-123087159
1948 Poinso F, Dubois B, Chatel C, . [Prospective assessment of children with pervasive developmental disorder after 2 years of day-hospital treatment]. Arch Pediatr. 2013 Jan;20(1):17–25. doi: 10.1016/j.arcped.2012.10.014. X-3, X-423219270
1949 Pooragha F, Kafi SM, Sotodeh SO. Comparing response inhibition and flexibility for two components of executive functioning in children with autism spectrum disorder and normal children. Iran J Pediatr. 2013 Jun;23(3):309–14. X-123795254
1950 Poot M. Towards identification of individual etiologies by resolving genomic and biological conundrums in patients with autism spectrum disorders. Mol Syndromol. 2013 Jun;4(5):213–26. doi: 10.1159/000350041. X-123885228
1951 Porges SW, Macellaio M, Stanfill SD, . Respiratory sinus arrhythmia and auditory processing in autism: modifiable deficits of an integrated social engagement system? Int J Psychophysiol. 2013 Jun;88(3):261–70. doi: 10.1016/j.ijpsycho.2012.11.009. X-123201146
1952 Post SG, Pomeroy J, Keirns CC, . Brief report: Stony Brook Guidelines on the ethics of the care of people with autism and their families. J Autism Dev Disord. 2013 Jun;43(6):1473–6. doi: 10.1007/s10803-012-1680-z. X-123086685
1953 Pratt DW, Warner JV, Williams MG. Genotyping FOXG1 Mutations in Patients with Clinical Evidence of the FOXG1 Syndrome. Mol Syndromol. 2013 Jan;3(6):284–7. doi: 10.1159/000345845. X-123599699
1954 Prigge MB, Lange N, Bigler ED, . Corpus Callosum Area in Children and Adults with Autism. Res Autism Spectr Disord. 2013;7(2):221–34. doi: 10.1016/j.rasd.2012.09.007. X-123130086
1955 Prigge MD, Bigler ED, Fletcher PT, . Longitudinal Heschl’s gyrus growth during childhood and adolescence in typical development and autism. Autism Res. 2013 Apr;6(2):78–90. doi: 10.1002/aur.1265. X-123436773
1956 Pritchard JK. Skills. Behav Anal Pract. 2013 Spring;6(1):96–100. X-125729511
1957 Puzzo I, Cooper NR, Cantarella S, . The effect of rTMS over the inferior parietal lobule on EEG sensorimotor reactivity differs according to self-reported traits of autism in typically developing individuals. Brain Res. 2013 Dec 6;1541:33–41. doi: 10.1016/j.brainres.2013.10.016. X-124161404
1958 Rada RE. Treatment needs and adverse events related to dental treatment under general anesthesia for individuals with autism. Intellect Dev Disabil. 2013 Aug;51(4):246–52. doi: 10.1352/1934-9556-51.4.246. X-123909586
1959 Radonovich KJ, Fournier KA, Hass CJ. Relationship between postural control and restricted, repetitive behaviors in autism spectrum disorders. Front Integr Neurosci. 2013;7:28. doi: 10.3389/fnint.2013.00028. X-123675326
1960 Radulescu E, Minati L, Ganeshan B, . Abnormalities in fronto-striatal connectivity within language networks relate to differences in grey-matter heterogeneity in Asperger syndrome. Neuroimage Clin. 2013;2:716–26. doi: 10.1016/j.nicl.2013.05.010. X-124179823
1961 Rafferty A, Martin J, Strachan D, . Cochlear implantation in children with complex needs - outcomes. Cochlear Implants Int. 2013 Mar;14(2):61–6. doi: 10.1179/1754762810y.0000000009. X-122333941
1962 Rai D, Lee BK, Dalman C, . Parental depression, maternal antidepressant use during pregnancy, and risk of autism spectrum disorders: population based case-control study. Bmj. 2013;346:f2059. doi: 10.1136/bmj.f2059. X-123604083
1963 Ramirez PL, Barnhill K, Gutierrez A, . Improvements in Behavioral Symptoms following Antibiotic Therapy in a 14-Year-Old Male with Autism. Case Rep Psychiatry. 2013;2013:239034. doi: 10.1155/2013/239034. X-1, X-3, X-423853732
1964 Ramsey JM, Guest PC, Broek JA, . Identification of an age-dependent biomarker signature in children and adolescents with autism spectrum disorders. Mol Autism. 2013;4(1):27. doi: 10.1186/2040-2392-4-27. X-123915542
1965 Ranft P. Ruminations on Hildegard of Bingen (1098–1179) and autism. J Med Biogr. 2013 Jul 29;22(2):107–15. doi: 10.1177/0967772013479283. X-124585581
1966 Rapp JT, Swanson G, Sheridan SM, . Immediate and Subsequent Effects of Matched and Unmatched Stimuli on Targeted Vocal Stereotypy and Untargeted Motor Stereotypy. Behavior Modification. 2013;37(4):543–67 25p. doi: 10.1177/0145445512461650. Language: English. Entry Date: 20130618. Revision Date: 20150711. Publication Type: Journal Article. X-1, X-323144173
1967 Rattaz C, Dubois A, Michelon C, . How do children with autism spectrum disorders express pain? A comparison with developmentally delayed and typically developing children. Pain. 2013 Oct;154(10):2007–13. doi: 10.1016/j.pain.2013.06.011. X-124040973
1968 Reed P, Watts H, Truzoli R. Flexibility in young people with autism spectrum disorders on a card sort task. Autism: The International Journal of Research & Practice. 2013;17(2):162–71 10p. doi: 10.1177/1362361311409599. Language: English. Entry Date: 20130321. Revision Date: 20150711. Publication Type: Journal Article. X-121690212
1969 Reed SR, Stahmer AC, Suhrheinrich J, . Stimulus overselectivity in typical development: implications for teaching children with autism. J Autism Dev Disord. 2013 Jun;43(6):1249–57. doi: 10.1007/s10803-012-1658-x. X-123065100
1970 Reeves GM, Keeton C, Correll CU, . Improving metabolic parameters of antipsychotic child treatment (IMPACT) study: rationale, design, and methods. Child Adolesc Psychiatry Ment Health. 2013;7(1):31. doi: 10.1186/1753-2000-7-31. X-1, X-223947389
1971 Reimer B, Fried R, Mehler B, . Brief Report: Examining Driving Behavior in Young Adults with High Functioning Autism Spectrum Disorders: A Pilot Study Using a Driving Simulation Paradigm. Journal of Autism & Developmental Disorders. 2013;43(9):2211–7 7p. doi: 10.1007/s10803-013-1764-4. Language: English. Entry Date: 20130820. Revision Date: 20150711. Publication Type: Journal Article. X-123338532
1972 Reynell C, Harris JJ. The BOLD signal and neurovascular coupling in autism. Dev Cogn Neurosci. 2013 Oct;6:72–9. doi: 10.1016/j.dcn.2013.07.003. X-123917518
1973 Riby DM, Hancock PJ, Jones N, . Spontaneous and cued gaze-following in autism and Williams syndrome. J Neurodev Disord. 2013;5(1):13. doi: 10.1186/1866-1955-5-13. X-123663405
1974 Rieger A, McGrail JP. Coping humor and family functioning in parents of children with disabilities. Rehabil Psychol. 2013 Feb;58(1):89–97. doi: 10.1037/a0031556. X-123438005
1975 Rieske RD, Matson JL, Davis TE, 3rd, . Examination and validation of a measure of anxiety specific to children with autism spectrum disorders. Dev Neurorehabil. 2013;16(1):9–16. doi: 10.3109/17518423.2012.705909. X-123030738
1976 Roberts TP, Lanza MR, Dell J, . Maturational differences in thalamocortical white matter microstructure and auditory evoked response latencies in autism spectrum disorders. Brain Res. 2013 Nov 6;1537:79–85. doi: 10.1016/j.brainres.2013.09.011. X-124055954
1977 Robertson RE, Wehby JH, King SM. Increased parent reinforcement of spontaneous requests in children with autism spectrum disorder: effects on problem behavior. Res Dev Disabil. 2013 Mar;34(3):1069–82. doi: 10.1016/j.ridd.2012.12.011. X-3, X-423299185
1978 Rogers TD, Dickson PE, McKimm E, . Reorganization of circuits underlying cerebellar modulation of prefrontal cortical dopamine in mouse models of autism spectrum disorder. Cerebellum. 2013 Aug;12(4):547–56. doi: 10.1007/s12311-013-0462-2. X-123436049
1979 Roke Y, van Harten PN, Franke B, . The effect of the Taq1A variant in the dopamine D(2) receptor gene and common CYP2D6 alleles on prolactin levels in risperidone-treated boys. Pharmacogenet Genomics. 2013 Sep;23(9):487–93. doi: 10.1097/FPC.0b013e3283647c33. X-1, X-323851570
1980 Ron D. Candida mix? a case study and information about Candidemia. Similia: Journal of the Australian Homoeopathic Association. 2013;25(1):12–4 3p. Language: English. Entry Date: 20130726. Revision Date: 20150712. Publication Type: Journal Article. X-1
1981 Ronconi L, Gori S, Ruffino M, . Zoom-out attentional impairment in children with autism spectrum disorder. Cortex: A Journal Devoted to the Study of the Nervous System & Behavior. 2013;49(4):1025–33 9p. doi: 10.1016/j.cortex.2012.03.005. Language: English. Entry Date: 20131011. Revision Date: 20150712. Publication Type: Journal Article. X-122503282
1982 Rosenberg RE, Law JK, Anderson C, . Survey of vaccine beliefs and practices among families affected by autism spectrum disorders. Clin Pediatr (Phila). 2013 Sep;52(9):871–4. doi: 10.1177/0009922812438435. X-122387922
1983 Rossignol DA. My experience learning about autism. Glob Adv Health Med. 2013 Nov;2(6):74–7. doi: 10.7453/gahmj.2013.090. X-124349885
1984 Roux AM, Shattuck PT, Cooper BP, . Postsecondary employment experiences among young adults with an autism spectrum disorder. J Am Acad Child Adolesc Psychiatry. 2013 Sep;52(9):931–9. doi: 10.1016/j.jaac.2013.05.019. X-123972695
1985 Roux G, Sofronoff K, Sanders M. A randomized controlled trial of group Stepping Stones Triple P: a mixed-disability trial. Fam Process. 2013 Sep;52(3):411–24. doi: 10.1111/famp.12016. X-124033239
1986 Ruble L, McGrew JH. Teacher and child predictors of achieving IEP goals of children with autism. J Autism Dev Disord. 2013 Dec;43(12):2748–63. doi: 10.1007/s10803-013-1884-x. X-1, X-323838728
1987 Ruble LA, McGrew JH, Toland MD, . A randomized controlled trial of COMPASS web-based and face-to-face teacher coaching in autism. J Consult Clin Psychol. 2013 Jun;81(3):566–72. doi: 10.1037/a0032003. X-123438314
1988 Ruble LA, Toland MD, Birdwhistell JL, . Preliminary Study of the Autism Self-Efficacy Scale for Teachers (ASSET). Res Autism Spectr Disord. 2013 Sep;7(9):1151–9. doi: 10.1016/j.rasd.2013.06.006. X-123976899
1989 Ruiz-Robledillo N, Moya-Albiol L. Self-reported health and cortisol awakening response in parents of people with asperger syndrome: the role of trait anger and anxiety, coping and burden. Psychol Health. 2013 Nov;28(11):1246–64. doi: 10.1080/08870446.2013.800517. X-123713979
1990 Ruskin DN, Svedova J, Cote JL, . Ketogenic diet improves core symptoms of autism in BTBR mice. PLoS One. 2013;8(6):e65021. doi: 10.1371/journal.pone.0065021. X-123755170
1991 Russell AJ, Jassi A, Fullana MA, . Cognitive behavior therapy for comorbid obsessive-compulsive disorder in high-functioning autism spectrum disorders: a randomized controlled trial. Depress Anxiety. 2013 Aug;30(8):697–708. doi: 10.1002/da.22053. X-123389964
1992 Russell-Smith S, Bayliss D, Maybery M, . Are the Autism and Positive Schizotypy Spectra Diametrically Opposed in Empathizing and Systemizing? Journal of Autism & Developmental Disorders. 2013;43(3):695–706 12p. doi: 10.1007/s10803-012-1614-9. Language: English. Entry Date: 20130225. Revision Date: 20150711. Publication Type: Journal Article. X-122829244
1993 Russo AJ. Decreased Epidermal Growth Factor (EGF) Associated with HMGB1 and Increased Hyperactivity in Children with Autism. Biomark Insights. 2013;8:35–41. doi: 10.4137/bmi.s11270. X-123645980
1994 Russo AJ. Correlation Between Hepatocyte Growth Factor (HGF) and Gamma-Aminobutyric Acid (GABA) Plasma Levels in Autistic Children. Biomark Insights. 2013;8:69–75. doi: 10.4137/bmi.s11448. X-123825437
1995 Rytterstrom P, Unosson M, Arman M. Care culture as a meaning-making process: a study of a mistreatment investigation. Qual Health Res. 2013 Sep;23(9):1179–87. doi: 10.1177/1049732312470760. X-123264536
1996 Saemundsen E, Magnusson P, Georgsdottir I, . Prevalence of autism spectrum disorders in an Icelandic birth cohort. BMJ Open. 2013;3(6) doi: 10.1136/bmjopen-2013-002748. X-1
1997 Sahu JK, Gulati S, Sapra S, . Effectiveness and safety of donepezil in boys with fragile x syndrome: a double-blind, randomized, controlled pilot study. J Child Neurol. 2013 May;28(5):570–5. doi: 10.1177/0883073812449381. X-122752489
1998 Sakurai T. [Drug development targeting synaptic molecules - autism mouse models as an example]. Nihon Yakurigaku Zasshi. 2013 Sep;142(3):116–21. X-124025492
1999 Sallam K, Amr M. The use of the mini-mental state examination and the clock-drawing test for dementia in a tertiary hospital. J Clin Diagn Res. 2013 Mar;7(3):484–8. doi: 10.7860/jcdr/2013/4203.2803. X-123634401
2000 Salowitz N, Eccarius P, Karst J, . Brief Report: Visuo-spatial Guidance of Movement during Gesture Imitation and Mirror Drawing in Children with Autism Spectrum Disorders. Journal of Autism & Developmental Disorders. 2013;43(4):985–95 11p. doi: 10.1007/s10803-012-1631-8. Language: English. Entry Date: 20130321. Revision Date: 20150711. Publication Type: Journal Article. X-122898762
2001 Samadi SA, McConkey R, Kelly G. Enhancing parental well-being and coping through a family-centred short course for Iranian parents of children with an autism spectrum disorder. Autism. 2013 Jan;17(1):27–43. doi: 10.1177/1362361311435156. X-122297201
2002 Sandell C, Kjellberg A, Taylor RR. Participating in diagnostic experience: adults with neuropsychiatric disorders. Scand J Occup Ther. 2013 Mar;20(2):136–42. doi: 10.3109/11038128.2012.741621. X-123152985
2003 Sandiford GA, Mainess KJ, Daher NS. A pilot study on the efficacy of melodic based communication therapy for eliciting speech in nonverbal children with autism. J Autism Dev Disord. 2013 Jun;43(6):1298–307. doi: 10.1007/s10803-012-1672-z. X-423065117
2004 Sandin S, Nygren KG, Iliadou A, . Autism and mental retardation among offspring born after in vitro fertilization. Jama. 2013 Jul 3;310(1):75–84. doi: 10.1001/jama.2013.7222. X-123821091
2005 Santini E, Huynh TN, MacAskill AF, . Exaggerated translation causes synaptic and behavioural aberrations associated with autism. Nature. 2013 Jan 17;493(7432):411–5. doi: 10.1038/nature11782. X-123263185
2006 Sarkamo T, Tervaniemi M, Huotilainen M. Music perception and cognition: development, neural basis, and rehabilitative use of music. Wiley Interdiscip Rev Cogn Sci. 2013 Jul;4(4):441–51. doi: 10.1002/wcs.1237. X-126304229
2007 Sasson NJ, Lam KS, Parlier M, . Autism and the broad autism phenotype: familial patterns and intergenerational transmission. J Neurodev Disord. 2013;5(1):11. doi: 10.1186/1866-1955-5-11. X-123639131
2008 Saunders JA, Tatard-Leitman VM, Suh J, . Knockout of NMDA receptors in parvalbumin interneurons recreates autism-like phenotypes. Autism Res. 2013 Apr;6(2):69–77. doi: 10.1002/aur.1264. X-123441094
2009 Sawa T, Kodaira M, Oiji A, . Dysfunction of orbitofrontal and dorsolateral prefrontal cortices in children and adolescents with high-functioning pervasive developmental disorders. Ann Gen Psychiatry. 2013;12(1):31. doi: 10.1186/1744-859x-12-31. X-124103490
2010 Scahill L, Hallett V, Aman MG, . Brief Report: social disability in autism spectrum disorder: results from Research Units on Pediatric Psychopharmacology (RUPP) Autism Network trials. J Autism Dev Disord. 2013 Mar;43(3):739–46. doi: 10.1007/s10803-012-1689-3.23104617
2011 Schafer EC, Mathews L, Mehta S, . Personal FM systems for children with autism spectrum disorders (ASD) and/or attention-deficit hyperactivity disorder (ADHD): an initial investigation. J Commun Disord. 2013 Jan–Feb;46(1):30–52. doi: 10.1016/j.jcomdis.2012.09.002. X-3, X-423123089
2012 Schlosser RW, Laubscher E, Sorce J, . Implementing directives that involve prepositions with children with autism: a comparison of spoken cues with two types of augmented input. Augment Altern Commun. 2013 Jun;29(2):132–45. doi: 10.3109/07434618.2013.784928. X-1, X-423705815
2013 Sears KM, Blair KS, Iovannone R, . Using the prevent-teach-reinforce model with families of young children with ASD. J Autism Dev Disord. 2013 May;43(5):1005–16. doi: 10.1007/s10803-012-1646-1. X-3, X-422972500
2014 Seery AM, Vogel-Farley V, Tager-Flusberg H, . Atypical lateralization of ERP response to native and non-native speech in infants at risk for autism spectrum disorder. Dev Cogn Neurosci. 2013 Jul;5:10–24. doi: 10.1016/j.dcn.2012.11.007. X-123287023
2015 Selim ME, Al-Ayadhi LY. Possible ameliorative effect of breastfeeding and the uptake of human colostrum against coeliac disease in autistic rats. World J Gastroenterol. 2013 Jun 7;19(21):3281–90. doi: 10.3748/wjg.v19.i21.3281. X-123745030
2016 Semansky RM, Xie M, Lawer LJ, . How states use Medicaid to fund community-based services to children with autism spectrum disorders. Psychiatr Serv. 2013 Oct;64(10):1051–5. doi: 10.1176/appi.ps.201200390. X-124081405
2017 Sgado P, Provenzano G, Dassi E, . Transcriptome profiling in engrailed-2 mutant mice reveals common molecular pathways associated with autism spectrum disorders. Mol Autism. 2013;4(1):51. doi: 10.1186/2040-2392-4-51. X-124355397
2018 Shadravan F. Sex bias in copy number variation of olfactory receptor gene family depends on ethnicity. Front Genet. 2013;4:32. doi: 10.3389/fgene.2013.00032. X-123503716
2019 Sharma A, Gokulchandran N, Sane H, . Autologous bone marrow mononuclear cell therapy for autism: an open label proof of concept study. Stem Cells Int. 2013;2013:623875. doi: 10.1155/2013/623875. X-3, X-424062774
2020 Sharpe MA, Gist TL, Baskin DS. Alterations in sensitivity to estrogen, dihydrotestosterone, and xenogens in B-lymphocytes from children with autism spectrum disorder and their unaffected twins/siblings. J Toxicol. 2013;2013:159810. doi: 10.1155/2013/159810. X-124363669
2021 Sharpe MA, Gist TL, Baskin DS. B-lymphocytes from a population of children with autism spectrum disorder and their unaffected siblings exhibit hypersensitivity to thimerosal. J Toxicol. 2013;2013:801517. doi: 10.1155/2013/801517. X-123843785
2022 Shiokawa S, Kitamura K, Fujii T, . [Support provided by public health nurses to adolescents with pervasive developmental disorders and their families]. Nihon Koshu Eisei Zasshi. 2013;60(11):705–14. X-124418919
2023 Siller M, Hutman T, Sigman M. A parent-mediated intervention to increase responsive parental behaviors and child communication in children with ASD: a randomized clinical trial. J Autism Dev Disord. 2013 Mar;43(3):540–55. doi: 10.1007/s10803-012-1584-y. X-122825926
2024 Silverman JL, Oliver CF, Karras MN, . AMPAKINE enhancement of social interaction in the BTBR mouse model of autism. Neuropharmacology. 2013 Jan;64:268–82. doi: 10.1016/j.neuropharm.2012.07.013. X-122801296
2025 Simmeborn Fleischer A, Adolfsson M, Granlund M. Students with disabilities in higher education - perceptions of support needs and received support: a pilot study. Int J Rehabil Res. 2013 Dec;36(4):330–8. doi: 10.1097/MRR.0b013e328362491c. X-123722568
2026 Simon DM, Corbett BA. Examining associations between anxiety and cortisol in high functioning male children with autism. J Neurodev Disord. 2013;5(1):32. doi: 10.1186/1866-1955-5-32. X-124216056
2027 Singh GK, Kenney MK, Ghandour RM, . Mental Health Outcomes in US Children and Adolescents Born Prematurely or with Low Birthweight. Depress Res Treat. 2013;2013:570743. doi: 10.1155/2013/570743. X-124324882
2028 Singh S. Valproate use during pregnancy was linked to autism spectrum disorder and childhood autism in offspring. ACP Journal Club. 2013;159(4):1- p. Language: English. Entry Date: 20130927. Revision Date: 20150711. Publication Type: Journal Article. X-1
2029 Slotkin TA, Seidler FJ. Terbutaline impairs the development of peripheral noradrenergic projections: potential implications for autism spectrum disorders and pharmacotherapy of preterm labor. Neurotoxicol Teratol. 2013 Mar–Apr;36:91–6. doi: 10.1016/j.ntt.2012.07.003. X-122813780
2030 Soorya L, Kolevzon A, Zweifach J, . Prospective investigation of autism and genotype-phenotype correlations in 22q13 deletion syndrome and SHANK3 deficiency. Mol Autism. 2013;4(1):18. doi: 10.1186/2040-2392-4-18. X-123758760
2031 Sorensen MJ, Gronborg TK, Christensen J, . Antidepressant exposure in pregnancy and risk of autism spectrum disorders. Clin Epidemiol. 2013;5:449–59. doi: 10.2147/clep.s53009. X-124255601
2032 Souchay C, Wojcik DZ, Williams HL, . Recollection in adolescents with Autism Spectrum Disorder. Cortex: A Journal Devoted to the Study of the Nervous System & Behavior. 2013;49(6):1598–609 12p. doi: 10.1016/j.cortex.2012.07.011. Language: English. Entry Date: 20140131. Revision Date: 20150712. Publication Type: Journal Article. X-123107379
2033 Spek AA, van Ham NC, Nyklicek I. Mindfulness-based therapy in adults with an autism spectrum disorder: a randomized controlled trial. Res Dev Disabil. 2013 Jan;34(1):246–53. doi: 10.1016/j.ridd.2012.08.009. X-122964266
2034 Spencer D, Marshall J, Post B, . Psychotropic medication use and polypharmacy in children with autism spectrum disorders. Pediatrics. 2013 Nov;132(5):833–40. doi: 10.1542/peds.2012-3774. X-124144704
2035 Spencer TD, Kajian M, Petersen DB, . Effects of an Individualized Narrative Intervention on Children’s Storytelling and Comprehension Skills. Journal of Early Intervention. 2013;35(2):243–69 27p. doi: 10.1177/1053815114540002. Language: English. Entry Date: 20140110. Revision Date: 20150818. Publication Type: Journal Article. X-1, X-3
2036 Spilioti M, Evangeliou AE, Tramma D, . Evidence for treatable inborn errors of metabolism in a cohort of 187 Greek patients with autism spectrum disorder (ASD). Front Hum Neurosci. 2013;7:858. doi: 10.3389/fnhum.2013.00858. X-124399946
2037 Srinivasan SM, Bhat AN. A review of “music and movement” therapies for children with autism: embodied interventions for multisystem development. Front Integr Neurosci. 2013;7:22. doi: 10.3389/fnint.2013.00022. X-1, X-223576962
2038 Srinivasaraghavan R, Mahadevan S, Kattimani S. Impact of Comorbidity on Three Month Follow-up Outcome of Children with ADHD in a Child Guidance Clinic: Preliminary Report. Indian J Psychol Med. 2013 Oct;35(4):346–51. doi: 10.4103/0253-7176.122223. X-124379493
2039 Stadnick NA, Drahota A, Brookman-Frazee L. Parent Perspectives of an Evidence-Based Intervention for Children with Autism Served in Community Mental Health Clinics. J Child Fam Stud. 2013 Apr 1;22(3):414–22. doi: 10.1007/s10826-012-9594-0. X-324019736
2040 Stamova BS, Tian Y, Nordahl CW, . Evidence for differential alternative splicing in blood of young boys with autism spectrum disorders. Mol Autism. 2013;4(1):30. doi: 10.1186/2040-2392-4-30. X-124007566
2041 Staples K. Commentary: The Motor Skills of 7–10 Year Old Children Diagnosed with ASD. Are the Comparison Groups and Assessments Being Used Appropriate for the Research Questions Being Asked?…Whyatt CP, Craig CM. Motor skills in children aged 7–19 years diagnosed with autism spectrum disorder. Journal of Autism and Developmental Disorders 2012; 42:1799–1809. Journal of Autism & Developmental Disorders. 2013;43(11):2732–6 5p. doi: 10.1007/s10803-013-1809-8. Language: English. Entry Date: 20131015. Revision Date: 20150711. Publication Type: Journal Article. X-123504378
2042 Starck T, Nikkinen J, Rahko J, . Resting state fMRI reveals a default mode dissociation between retrosplenial and medial prefrontal subnetworks in ASD despite motion scrubbing. Front Hum Neurosci. 2013;7:802. doi: 10.3389/fnhum.2013.00802. X-124319422
2043 Stein LI, Polido JC, Cermak SA. Oral care and sensory over-responsivity in children with autism spectrum disorders. Pediatr Dent. 2013 May–Jun;35(3):230–5. X-123756306
2044 Steiner AM, Gengoux GW, Klin A, . Pivotal response treatment for infants at-risk for autism spectrum disorders: a pilot study. J Autism Dev Disord. 2013 Jan;43(1):91–102. doi: 10.1007/s10803-012-1542-8. X-3, X-422573001
2045 Steinman G, Mankuta D. Breastfeeding as a possible deterrent to autism--a clinical perspective. Med Hypotheses. 2013 Dec;81(6):999–1001. doi: 10.1016/j.mehy.2013.09.013. X-124099931
2046 Storch EA, Arnold EB, Lewin AB, . The effect of cognitive-behavioral therapy versus treatment as usual for anxiety in children with autism spectrum disorders: a randomized, controlled trial. J Am Acad Child Adolesc Psychiatry. 2013 Feb;52(2):132–42.e2. doi: 10.1016/j.jaac.2012.11.007. X-123357440
2047 Strickland DC, Coles CD, Southern LB. JobTIPS: a transition to employment program for individuals with autism spectrum disorders. J Autism Dev Disord. 2013 Oct;43(10):2472–83. doi: 10.1007/s10803-013-1800-4. X-123494559
2048 Stroganova TA, Kozunov VV, Posikera IN, . Abnormal pre-attentive arousal in young children with autism spectrum disorder contributes to their atypical auditory behavior: an ERP study. PLoS One. 2013;8(7):e69100. doi: 10.1371/journal.pone.0069100. X-1, X-323935931
2049 Sugarman LI, Garrison BL, Williford KL. Symptoms as solutions: hypnosis and biofeedback for autonomic regulation in autism spectrum disorders. Am J Clin Hypn. 2013 Oct;56(2):152–73. X-124665817
2050 Suhrheinrich J, Stahmer AC, Reed S, . Implementation challenges in translating pivotal response training into community settings. J Autism Dev Disord. 2013 Dec;43(12):2970–6. doi: 10.1007/s10803-013-1826-7. X-123619949
2051 Sun C, Xia W, Zhao Y, . Nutritional status survey of children with autism and typically developing children aged 4–6 years in Heilongjiang Province, China. J Nutr Sci. 2013;2:e16. doi: 10.1017/jns.2013.9. X-125191564
2052 Sun X, Allison C, Auyeung B, . Service provision for autism in mainland China: preliminary mapping of service pathways. Soc Sci Med. 2013 Dec;98:87–94. doi: 10.1016/j.socscimed.2013.08.016. X-124331886
2053 Sun X, Allison C, Auyeung B, . Service provision for autism in mainland China: a service providers’ perspective. Res Dev Disabil. 2013 Jan;34(1):440–51. doi: 10.1016/j.ridd.2012.08.010. X-123041658
2054 Sun X, Allison C, Matthews FE, . Prevalence of autism in mainland China, Hong Kong and Taiwan: a systematic review and meta-analysis. Mol Autism. 2013;4(1):7. doi: 10.1186/2040-2392-4-7. X-123570419
2055 Suren P, Roth C, Bresnahan M, . Association between maternal use of folic acid supplements and risk of autism spectrum disorders in children. Jama. 2013 Feb 13;309(6):570–7. doi: 10.1001/jama.2012.155925. X-123403681
2056 Surette S, Vanderjagt L, Vohra S. Surveys of complementary and alternative medicine usage: a scoping study of the paediatric literature. Complement Ther Med. 2013 Apr;21(Suppl 1):S48–53. doi: 10.1016/j.ctim.2011.08.006. X-123578917
2057 Tachibana M, Kagitani-Shimono K, Mohri I, . Long-term administration of intranasal oxytocin is a safe and promising therapy for early adolescent boys with autism spectrum disorders. J Child Adolesc Psychopharmacol. 2013 Mar;23(2):123–7. doi: 10.1089/cap.2012.0048. X-1, X-3, X-423480321
2058 Tahmasebi Birgani MJ, Behrouz MA, Aliakbari S, . Determination of square equivalent field for rectangular field in electron therapy. J Med Phys. 2013 Apr;38(2):82–6. doi: 10.4103/0971-6203.111317. X-123776311
2059 Tajeran M, Baghbani F, Hassanzadeh-Nazarabadi M. A Case of Autism with Ring Chromosome 14. Iran J Public Health. 2013 Nov;42(11):1316–20. X-126171345
2060 Takahashi J, Gyoba J, Yamawaki N. Brief Report: Effect of Spatial Complexity on Visual Short-Term Memory and Self-Reported Autistic-Like Traits in Typically Developed Individuals. Journal of Autism & Developmental Disorders. 2013;43(7):1725–31 7p. doi: 10.1007/s10803-012-1711-9. Language: English. Entry Date: 20130620. Revision Date: 20150711. Publication Type: Journal Article. X-123132273
2061 Taliou A, Zintzaras E, Lykouras L, . An open-label pilot study of a formulation containing the anti-inflammatory flavonoid luteolin and its effects on behavior in children with autism spectrum disorders. Clin Ther. 2013 May;35(5):592–602. doi: 10.1016/j.clinthera.2013.04.006. X-323688534
2062 Tamas D, Markovic S, Milankov V. Systemic multimodal approach to speech therapy treatment in autistic children. Med Pregl. 2013 May–Jun;66(5–6):233–9. X-1, X-323888732
2063 Tchanturia K, Smith E, Weineck F, . Exploring autistic traits in anorexia: a clinical study. Mol Autism. 2013;4(1):44. doi: 10.1186/2040-2392-4-44. X-124220604
2064 Teng BL, Nonneman RJ, Agster KL, . Prosocial effects of oxytocin in two mouse models of autism spectrum disorders. Neuropharmacology. 2013 Sep;72:187–96. doi: 10.1016/j.neuropharm.2013.04.038. X-123643748
2065 Thakkar KB, Jain MM, Billa G, . A drug utilization study of psychotropic drugs prescribed in the psychiatry outpatient department of a tertiary care hospital. J Clin Diagn Res. 2013 Dec;7(12):2759–64. doi: 10.7860/jcdr/2013/6760.3885. X-124551631
2066 Thompson RM, Johnston S. Use of social stories to improve self-regulation in children with autism spectrum disorders. Phys Occup Ther Pediatr. 2013 Aug;33(3):271–84. doi: 10.3109/01942638.2013.768322. X-3, X-423437903
2067 Ting L. SENSORY PROCESSING AND MOTOR SKILL PERFORMANCE IN ELEMENTARY SCHOOL CHILDREN WITH AUTISM SPECTRUM DISORDER. Perceptual & Motor Skills. 2013;116(1):197–209 13p. doi: 10.2466/10.25.PMS.116.1.197-209. Language: English. Entry Date: 20130906. Revision Date: 20150711. Publication Type: Journal Article. X-123829146
2068 Tomizawa Y, Sato Y, Yokoyama H. [Parent training for parents of children with attention deficit/hyperactivity disorder (AD/HD) does not improve the behavior of children with both high-functioning pervasive developmental disorder and AD/HD]. No To Hattatsu. 2013 Jan;45(1):33–7. X-323593743
2069 Tostes MH, Polonini HC, Mendes R, . Fatty acid and phospholipase A2 plasma levels in children with autism. Trends Psychiatry Psychother. 2013;35(1):76–80. X-125923188
2070 Travers B, Powell P, Mussey J, . Spatial and Identity Cues Differentially Affect Implicit Contextual Cueing in Adolescents and Adults with Autism Spectrum Disorder. Journal of Autism & Developmental Disorders. 2013;43(10):2393–404 12p. doi: 10.1007/s10803-013-1787-x. Language: English. Entry Date: 20130921. Revision Date: 20150711. Publication Type: Journal Article. X-123417264
2071 Treasure J. Coherence and other autistic spectrum traits and eating disorders: building from mechanism to treatment. The Birgit Olsson lecture. Nord J Psychiatry. 2013 Feb;67(1):38–42. doi: 10.3109/08039488.2012.674554. X-122468644
2072 Trevarthen C, Delafield-Butt JT. Autism as a developmental disorder in intentional movement and affective engagement. Front Integr Neurosci. 2013;7:49. doi: 10.3389/fnint.2013.00049. X-123882192
2073 Trontel HG, Duffield TC, Bigler ED, . Fusiform correlates of facial memory in autism. Behav Sci (Basel). 2013;3(3):348–71. doi: 10.3390/bs3030348. X-124761228
2074 Tunc-Ozcan E, Ullmann TM, Shukla PK, . Low-dose thyroxine attenuates autism-associated adverse effects of fetal alcohol in male offspring’s social behavior and hippocampal gene expression. Alcohol Clin Exp Res. 2013 Nov;37(11):1986–95. doi: 10.1111/acer.12183. X-123763370
2075 Uchiyama T. [Case study of 10 subjects diagnosed with autism spectrum disorders in adulthood and currently under long-term follow-up]. Seishin Shinkeigaku Zasshi. 2013;115(6):607–15. X-123944118
2076 Uddin LQ, Supekar K, Menon V. Reconceptualizing functional brain connectivity in autism from a developmental perspective. Front Hum Neurosci. 2013;7:458. doi: 10.3389/fnhum.2013.00458. X-123966925
2077 Ulate-Campos A, Benavides-Lara A, Hernandez L. [Characterisation of the paediatric population of Costa Rica with tuberous sclerosis and a description of the behaviour of the associated epilepsy]. Rev Neurol. 2013 Dec 1;57(11):489–94. X-124265142
2078 Ung D, Wood JJ, Ehrenreich-May J, . Clinical characteristics of high-functioning youth with autism spectrum disorder and anxiety. Neuropsychiatry (London). 2013 Apr;3(2) doi: 10.2217/npy.13.9. X-1
2079 van der Meer JM, Harfterkamp M, van de Loo-Neus G, . A randomized, double-blind comparison of atomoxetine and placebo on response inhibition and interference control in children and adolescents with autism spectrum disorder and comorbid attention-deficit/hyperactivity disorder symptoms. J Clin Psychopharmacol. 2013 Dec;33(6):824–7. doi: 10.1097/JCP.0b013e31829c764f.24018545
2080 van der Meer L, Kagohara D, Roche L, . Teaching multi-step requesting and social communication to two children with autism spectrum disorders with three AAC options. Augment Altern Commun. 2013 Sep;29(3):222–34. doi: 10.3109/07434618.2013.815801. X-3, X-423879660
2081 van Gelder MM, Bretveld RW, Roukema J, . Rationale and design of the PRegnancy and Infant DEvelopment (PRIDE) Study. Paediatr Perinat Epidemiol. 2013 Jan;27(1):34–43. doi: 10.1111/ppe.12023. X-123215710
2082 van Steensel FJ, Bogels SM, de Bruin EI. Psychiatric Comorbidity in Children with Autism Spectrum Disorders: A Comparison with Children with ADHD. J Child Fam Stud. 2013 Apr;22(3):368–76. doi: 10.1007/s10826-012-9587-z. X-123524401
2083 Vaz I. Visual symbols in healthcare settings for children with learning disabilities and autism spectrum disorder. Br J Nurs. 2013 Feb 14–28;22(3):156–9. doi: 10.12968/bjon.2013.22.3.156. X-123411823
2084 Velmeshev D, Magistri M, Faghihi MA. Expression of non-protein-coding antisense RNAs in genomic regions related to autism spectrum disorders. Mol Autism. 2013;4(1):32. doi: 10.1186/2040-2392-4-32. X-124007600
2085 Vismara LA, McCormick C, Young GS, . Preliminary findings of a telehealth approach to parent training in autism. J Autism Dev Disord. 2013 Dec;43(12):2953–69. doi: 10.1007/s10803-013-1841-8. X-1, X-323677382
2086 Visser E, Zwiers MP, Kan CC, . Atypical vertical sound localization and sound-onset sensitivity in people with autism spectrum disorders. J Psychiatry Neurosci. 2013 Nov;38(6):398–406. doi: 10.1503/jpn.120177. X-124148845
2087 Visser JC, Rommelse N, Vink L, . Narrowly versus broadly defined autism spectrum disorders: differences in pre- and perinatal risk factors. J Autism Dev Disord. 2013 Jul;43(7):1505–16. doi: 10.1007/s10803-012-1678-6. X-123076505
2088 Vivanti G, Dissanayake C, Zierhut C, . Brief report: Predictors of outcomes in the Early Start Denver Model delivered in a group setting. J Autism Dev Disord. 2013 Jul;43(7):1717–24. doi: 10.1007/s10803-012-1705-7. X-1, X-323124361
2089 Vladescu JC, Kodak TM. Increasing instructional efficiency by presenting additional stimuli in learning trials for children with autism spectrum disorders. J Appl Behav Anal. 2013 Dec;46(4):805–16. doi: 10.1002/jaba.70. X-3, X-424114346
2090 Wacker DP, Lee JF, Dalmau YC, . Conducting functional analyses of problem behavior via telehealth. J Appl Behav Anal. 2013 Spring;46(1):31–46. doi: 10.1002/jaba.29. X-324114083
2091 Wadell PM, Hagerman RJ, Hessl DR. FRAGILE X SYNDROME: PSYCHIATRIC MANIFESTATIONS, ASSESSMENT AND EMERGING THERAPIES. Curr Psychiatry Rev. 2013 Feb 1;9(1):53–8. doi: 10.2174/157340013805289644. X-125632275
2092 Wainer AL, Ingersoll BR. Disseminating ASD interventions: a pilot study of a distance learning program for parents and professionals. J Autism Dev Disord. 2013 Jan;43(1):11–24. doi: 10.1007/s10803-012-1538-4. X-3, X-422547028
2093 Wake R, Miyaoka T, Inagaki T, . Yokukansan (TJ-54) for irritability associated with pervasive developmental disorder in children and adolescents: a 12-week prospective, open-label study. J Child Adolesc Psychopharmacol. 2013 Jun;23(5):329–36. doi: 10.1089/cap.2012.0108. X-323782127
2094 Walker G, Local J. On the intersection of phonetic detail and the organization of interaction: clinical connections. Clin Linguist Phon. 2013 Oct–Nov;27(10–11):770–83. doi: 10.3109/02699206.2013.813078. X-124067088
2095 Walters K, Thomson K. The history of behavior analysis in manitoba: a sparsely populated canadian province with an international influence on behavior analysis. Behav Anal. 2013 Spring;36(1):57–72. X-125729132
2096 Wan Y, Hu Q, Li T, . Prevalence of autism spectrum disorders among children in China: a systematic review. Shanghai Arch Psychiatry. 2013 Apr;25(2):70–80. doi: 10.3969/j.issn.1002-0829.2013.02.003. X-124991138
2097 Wang CC, Lin HC, Chan YH, . 5-HT1A-receptor agonist modified amygdala activity and amygdala-associated social behavior in a valproate-induced rat autism model. Int J Neuropsychopharmacol. 2013 Oct;16(9):2027–39. doi: 10.1017/s1461145713000473. X-123823694
2098 Wang L, Mandell DS, Lawer L, . Healthcare service use and costs for autism spectrum disorder: a comparison between medicaid and private insurance. J Autism Dev Disord. 2013 May;43(5):1057–64. doi: 10.1007/s10803-012-1649-y. X-122965299
2099 Wang M, Reid D. Using the virtual reality-cognitive rehabilitation approach to improve contextual processing in children with autism. ScientificWorldJournal. 2013;2013:716890. doi: 10.1155/2013/716890. X-3, X-424324379
2100 Ward SC, Whalon K, Rusnak K, . The association between therapeutic horseback riding and the social communication and sensory reactions of children with autism. J Autism Dev Disord. 2013 Sep;43(9):2190–8. doi: 10.1007/s10803-013-1773-3. X-323371511
2101 Waris P, Lindberg N, Kettunen K, . The relationship between Asperger’s syndrome and schizophrenia in adolescence. Eur Child Adolesc Psychiatry. 2013 Apr;22(4):217–23. doi: 10.1007/s00787-012-0338-x. X-123065028
2102 Warren Z, Vehorn A, Dohrmann E, . Brief report: Service implementation and maternal distress surrounding evaluation recommendations for young children diagnosed with autism. Autism. 2013 Nov;17(6):693–700. doi: 10.1177/1362361312453881. X-123045221
2103 Watts AC, Wilder DA, Gregory MK, . The effect of rules on differential reinforcement of other behavior. J Appl Behav Anal. 2013 Fall;46(3):680–4. doi: 10.1002/jaba.53. X-3, X-424114232
2104 Weiss JA, Viecili MA, Sloman L, . Direct and Indirect Psychosocial Outcomes for Children with Autism Spectrum Disorder and their Parents Following a Parent-involved Social Skills Group Intervention. J Can Acad Child Adolesc Psychiatry. 2013 Nov;22(4):303–9. X-1, X-324223050
2105 Weiss MJ, Moran MF, Parker ME, . Gait analysis of teenagers and young adults diagnosed with autism and severe verbal communication disorders. Front Integr Neurosci. 2013;7:33. doi: 10.3389/fnint.2013.00033. X-123730274
2106 Werner S, Shulman C. Subjective well-being among family caregivers of individuals with developmental disabilities: the role of affiliate stigma and psychosocial moderating variables. Res Dev Disabil. 2013 Nov;34(11):4103–14. doi: 10.1016/j.ridd.2013.08.029. X-124055712
2107 White SJ. The Triple I Hypothesis: taking another(‘s) perspective on executive dysfunction in autism. J Autism Dev Disord. 2013 Jan;43(1):114–21. doi: 10.1007/s10803-012-1550-8. X-122584617
2108 White SW, Ollendick T, Albano AM, . Randomized controlled trial: Multimodal Anxiety and Social Skill Intervention for adolescents with autism spectrum disorder. J Autism Dev Disord. 2013 Feb;43(2):382–94. doi: 10.1007/s10803-012-1577-x. X-1, X-322735897
2109 Whitehouse AJ. Complementary and alternative medicine for autism spectrum disorders: Rationale, safety and efficacy. Journal of Paediatrics & Child Health. 2013;49(9):E438–42 1p. doi: 10.1111/jpc.12242. Language: English. Entry Date: 20140516. Revision Date: 20150710. Publication Type: Journal Article. Journal Subset: Australia & New Zealand. X-1, X-223682728
2110 Whyte EM, Nelson KE, Khan KS. Learning of idiomatic language expressions in a group intervention for children with autism. Autism. 2013 Jul;17(4):449–64. doi: 10.1177/1362361311422530. X-3, X-422087041
2111 Williams D, Payne H, Marshall C. Non-word Repetition Impairment in Autism and Specific Language Impairment: Evidence for Distinct Underlying Cognitive Causes. Journal of Autism & Developmental Disorders. 2013;43(2):404–17 14p. doi: 10.1007/s10803-012-1579-8. Language: English. Entry Date: 20130128. Revision Date: 20150711. Publication Type: Journal Article. X-122733298
2112 Williams K, Brignell A, Randall M, . Selective serotonin reuptake inhibitors (SSRIs) for autism spectrum disorders (ASD). Cochrane Database of Systematic Reviews. 2013(8):N.PAG-N.PAG 1p. Language: English. Entry Date: 20101029. Revision Date: 20150711. Publication Type: Journal Article. X-2
2113 Williamson RL, Casey LB, Robertson JS, . Video self-modeling in children with autism: a pilot study validating prerequisite skills and extending the utilization of VSM across skill sets. Assist Technol. 2013 Summer;25(2):63–71. doi: 10.1080/10400435.2012.712604. X-1, X-3, X-423923688
2114 Wilson KP. Incorporating video modeling into a school-based intervention for students with autism spectrum disorders. Lang Speech Hear Serv Sch. 2013 Jan;44(1):105–17. doi: 10.1044/0161-1461(2012/11-0098). X-1, X-223087158
2115 Wincik S. Learning from Katie. Nursing. 2013 Jul;43(7):40–1. doi: 10.1097/01.nurse.0000431138.05404.70. X-1
2116 Wolff JJ, Hazlett HC, Lightbody AA, . Repetitive and self-injurious behaviors: associations with caudate volume in autism and fragile X syndrome. J Neurodev Disord. 2013;5(1):12. doi: 10.1186/1866-1955-5-12. X-123639144
2117 Wolff JJ, Hupp SC, Symons FJ. Brief report: Avoidance extinction as treatment for compulsive and ritual behavior in autism. J Autism Dev Disord. 2013 Jul;43(7):1741–6. doi: 10.1007/s10803-012-1721-7. X-123179345
2118 Won H, Mah W, Kim E. Autism spectrum disorder causes, mechanisms, and treatments: focus on neuronal synapses. Front Mol Neurosci. 2013;6:19. doi: 10.3389/fnmol.2013.00019. X-1, X-223935565
2119 Xie Q, Tang J, Xu Y, . [Clinical observation of aripiprazole in the treatment of autism]. Zhongguo Dang Dai Er Ke Za Zhi. 2013 Apr;15(4):294–7. X-323607954
2120 Yakubova G, Taber-Doughty T. Brief Report: Learning Via the Electronic Interactive Whiteboard for Two Students with Autism and a Student with Moderate Intellectual Disability. Journal of Autism & Developmental Disorders. 2013;43(6):1465–72 8p. doi: 10.1007/s10803-012-1682-x. Language: English. Entry Date: 20130603. Revision Date: 20150711. Publication Type: Journal Article. X-1, X-3, X-423080208
2121 Yamagata T, Sugie H. [Expert opinion: investigation of drug therapy in children with autistic symptoms]. No To Hattatsu. 2013 May;45(3):223–6. X-223785839
2122 Yanardag M, Akmanoglu N, Yilmaz I. The effectiveness of video prompting on teaching aquatic play skills for children with autism. Disabil Rehabil. 2013 Jan;35(1):47–56. doi: 10.3109/09638288.2012.687030. X-3, X-422624856
2123 Yazawa M, Dolmetsch RE. Modeling Timothy syndrome with iPS cells. J Cardiovasc Transl Res. 2013 Feb;6(1):1–9. doi: 10.1007/s12265-012-9444-x. X-123299782
2124 Yazdani S, Yee CT, Chung PJ. Factors predicting physical activity among children with special needs. Prev Chronic Dis. 2013;10:E119. doi: 10.5888/pcd10.120283. X-123866163
2125 Yoder PJ, Bottema-Beutel K, Woynaroski T, . Social communication intervention effects vary by dependent variable type in preschoolers with autism spectrum disorders. Evid Based Commun Assess Interv. 2013;7(4):150–74. doi: 10.1080/17489539.2014.917780. X-1, X-225346776
2126 Yoshimura Y, Kikuchi M, Shitamichi K, . Atypical brain lateralisation in the auditory cortex and language performance in 3- to 7-year-old children with high-functioning autism spectrum disorder: a child-customised magnetoencephalography (MEG) study. Mol Autism. 2013;4(1):38. doi: 10.1186/2040-2392-4-38. X-124103585
2127 Yuan Q, Liu YS, Yu YT, . [Treatment of autism children: observation on efficacy of behavior training with retention of needles on head]. Zhongguo Zhen Jiu. 2013 Jul;33(7):609–13. X-124032193
2128 Zarafshan H, Mohammadi MR, Ahmadi F, . Job Burnout among Iranian Elementary School Teachers of Students with Autism: a Comparative Study. Iran J Psychiatry. 2013 Mar;8(1):20–7. X-123682248
2129 Zerbo O, Iosif AM, Walker C, . Is maternal influenza or fever during pregnancy associated with autism or developmental delays? Results from the CHARGE (CHildhood Autism Risks from Genetics and Environment) study. J Autism Dev Disord. 2013 Jan;43(1):25–33. doi: 10.1007/s10803-012-1540-x. X-1, X-322562209
2130 Zhang XJ, Wu Q. [Effects of electroacupuncture at different acupoints on learning and memory ability and PSD-95 protein expression on hippocampus CA1 in rats with autism]. Zhongguo Zhen Jiu. 2013 Jul;33(7):627–31. X-124032199
2131 Zhang Y, Gao D, Kluetzman K, . The maternal autoimmune environment affects the social behavior of offspring. J Neuroimmunol. 2013 May 15;258(1–2):51–60. doi: 10.1016/j.jneuroim.2013.02.019. X-123537887
2132 [Integrated and coordinated measures to manage autistic spectrum disorders]. Vertex. 2014 Jul–Aug;25(116):295–8. X-1, X-2, X-325558493
2133 Autism. Nurs Stand. 2014 Mar 12–18;28(28):19. doi: 10.7748/ns2014.03.28.28.19.s25. X-2, X-3
2134 Improving autism care: the NICE quality standard. Perspect Public Health. 2014 Mar;134(2):64. doi: 10.1177/1757913914523909. X-524623750
2135 Accepted scientific research works (abstracts). Int J Yoga Therap. 2014 Sep;24:18–38. X-1
2136 e-Pediatrics Perspectives. Pediatrics. 2014;134(2):380–96 17p. Language: English. Entry Date: 20140807. Revision Date: 20150712. Publication Type: Journal Article. X-1, X-2
2137 Let’s Go Out to Eat! OT Practice. 2014;19:(2)10–3 4p. Language: English. Entry Date: 20140210. Revision Date: 20150820. Publication Type: Journal Article. X-1, X-2
2138 Lay Abstracts. Autism: The International Journal of Research & Practice. 2014;18(2):203–7 5p. doi: 10.1177/1362361313517447. Language: English. Entry Date: 20140128. Revision Date: 20150710. Publication Type: Journal Article. X-1
2139 Risperidone doesn’t affect core autistic traits, according to 10-year longitudinal study. Brown University Child & Adolescent Psychopharmacology Update. 2014;16(12):3–4 2p. Language: English. Entry Date: 20141203. Revision Date: 20150710. Publication Type: Journal Article. Journal Subset: Biomedical. X-1, X-2
2140 ON THE WEB. Nurse.com The Magazine (South). 2014;5(9):12- 1p. Language: English. Entry Date: 20141001. Revision Date: 20150712. Publication Type: Journal Article. X-1, X-2
2141 Four new Evidence Updates released by NICE. Guidelines in Practice. 2014;17(6):11- 1p. Language: English. Entry Date: 20140707. Revision Date: 20150712. Publication Type: Journal Article. X-1, X-2
2142 News. Journal of Psychosocial Nursing & Mental Health Services. 2014;52(6):17–57 41p. doi: 10.3928/02793695-20140501-88. Language: English. Entry Date: 20150224. Revision Date: 20150710. Publication Type: Journal Article. X-1, X-2
2143 Adjusted analysis finds no link between exposure to antidepressants, autism. Brown University Psychopharmacology Update. 2014;25(5):4–5 2p. Language: English. Entry Date: 20140414. Revision Date: 20150710. Publication Type: Journal Article. Journal Subset: Biomedical. X-1, X-2
2144 Oxytocin May Boost Social Skills in Children With ASD. ASHA Leader. 2014;19(2):15- 1p. Language: English. Entry Date: 20140206. Revision Date: 20150712. Publication Type: Journal Article. X-1, X-2
2145 Antispsychotics: ‘last option’ for people with autism. Nursing Standard. 2014;28(22):10- 1p. doi: 10.7748/ns2014.01.28.22.10.s11. Language: English. Entry Date: 20140131. Revision Date: 20150710. Publication Type: Journal Article. X-1, X-2
2146 RESEARCH ROUNDUP. Brown University Child & Adolescent Psychopharmacology Update. 2014;16(1):8- 1p. Language: English. Entry Date: 20131223. Revision Date: 20150710. Publication Type: Journal Article. X-1, X-2
2147 Research opportunities in the area of mental health promotion, prevention, and intervention for children and youth. Am J Occup Ther. 2014 Sep–Oct;68(5):610–2. doi: 10.5014/ajot.2014.685001. X-125184474
2148 Aasen G, Naerland T. Enhancing activity by means of tactile symbols: a study of a heterogeneous group of pupils with congenital blindness, intellectual disability and autism spectrum disorder. J Intellect Disabil. 2014 Mar;18(1):61–75. doi: 10.1177/1744629514522142. X-1, X-324591428
2149 Abbeduto L, McDuffie A, Thurman AJ. The fragile X syndrome-autism comorbidity: what do we really know? Front Genet. 2014;5:355. doi: 10.3389/fgene.2014.00355. X-125360144
2150 Abu Kuwaik G, Roberts W, Zwaigenbaum L, . Immunization uptake in younger siblings of children with autism spectrum disorder. Autism. 2014 Feb;18(2):148–55. doi: 10.1177/1362361312459111. X-123045216
2151 Ackerman S, Wenegrat J, Rettew D, . No increase in autism-associated genetic events in children conceived by assisted reproduction. Fertil Steril. 2014 Aug;102(2):388–93. doi: 10.1016/j.fertnstert.2014.04.020. X-124842673
2152 Adamsen D, Ramaekers V, Ho HT, . Autism spectrum disorder associated with low serotonin in CSF and mutations in the SLC29A4 plasma membrane monoamine transporter (PMAT) gene. Mol Autism. 2014;5:43. doi: 10.1186/2040-2392-5-43. X-125802735
2153 Ahmed SS, Unland T, Slaven JE, . Successful use of intravenous dexmedetomidine for magnetic resonance imaging sedation in autistic children. South Med J. 2014 Sep;107(9):559–64. doi: 10.14423/smj.0000000000000160. X-1, X-225188619
2154 Ahn K, An SS, Shugart YY, . Common polygenic variation and risk for childhood-onset schizophrenia. Mol Psychiatry. 2014 Dec 16 doi: 10.1038/mp.2014.158. X-1
2155 Ahn Y, Narous M, Tobias R, . The ketogenic diet modifies social and metabolic alterations identified in the prenatal valproic acid model of autism spectrum disorder. Dev Neurosci. 2014;36(5):371–80. doi: 10.1159/000362645. X-125011527
2156 Akins RS, Krakowiak P, Angkustsiri K, . Utilization patterns of conventional and complementary/alternative treatments in children with autism spectrum disorders and developmental disabilities in a population-based study. J Dev Behav Pediatr. 2014 Jan;35(1):1–10. doi: 10.1097/dbp.0000000000000013. X-1, X-324399100
2157 Alashrah S, Kandaiya S, Maalej N, . Skin dose measurements using radiochromic films, TLDS and ionisation chamber and comparison with Monte Carlo simulation. Radiat Prot Dosimetry. 2014 Dec;162(3):338–44. doi: 10.1093/rpd/nct315. X-124300340
2158 Alfawaz HA, Bhat RS, Al-Ayadhi L, . Protective and restorative potency of Vitamin D on persistent biochemical autistic features induced in propionic acid-intoxicated rat pups. BMC Complement Altern Med. 2014;14:416. doi: 10.1186/1472-6882-14-416. X-125344727
2159 Al-Ghamdi M, Al-Ayadhi L, El-Ansary A. Selected biomarkers as predictive tools in testing efficacy of melatonin and coenzyme Q on propionic acid - induced neurotoxicity in rodent model of autism. BMC Neurosci. 2014;15:34. doi: 10.1186/1471-2202-15-34. X-124568717
2160 Al-Hakbany M, Awadallah S, Al-Ayadhi L. The Relationship of HLA Class I and II Alleles and Haplotypes with Autism: A Case Control Study. Autism Res Treat. 2014;2014:242048. doi: 10.1155/2014/242048. X-124672722
2161 Allan N, Harden J. Parental decision-making in uptake of the MMR vaccination: a systematic review of qualitative literature. J Public Health (Oxf). 2014 Oct 8 doi: 10.1093/pubmed/fdu075. X-1
2162 Allegra M, Genovesi S, Maggia M, . Altered GABAergic markers, increased binocularity and reduced plasticity in the visual cortex of Engrailed-2 knockout mice. Front Cell Neurosci. 2014;8:163. doi: 10.3389/fncel.2014.00163. X-124987331
2163 Allen JL, Liu X, Pelkowski S, . Early postnatal exposure to ultrafine particulate matter air pollution: persistent ventriculomegaly, neurochemical disruption, and glial activation preferentially in male mice. Environ Health Perspect. 2014 Sep;122(9):939–45. doi: 10.1289/ehp.1307984. X-124901756
2164 Al-Maweri SA, Halboub ES, Al-Soneidar WA, . Oral lesions and dental status of autistic children in Yemen: A case-control study. J Int Soc Prev Community Dent. 2014 Dec;4(Suppl 3):S199–203. doi: 10.4103/2231-0762.149040. X-125625079
2165 Al-Sarraj Y, Al-Khair HA, Taha RZ, . Distal trisomy 10q syndrome, report of a patient with duplicated q24.31 - qter, autism spectrum disorder and unusual features. Clin Case Rep. 2014 Oct;2(5):201–5. doi: 10.1002/ccr3.94. X-125614812
2166 Altschuler TS. The developmental trajectory of contour integration in autism spectrum disorders; 2014.
2167 Al-Zaid FS, Alhader AA, Al-Ayadhi LY. Altered ghrelin levels in boys with autism: a novel finding associated with hormonal dysregulation. Sci Rep. 2014;4:6478. doi: 10.1038/srep06478. X-125257829
2168 Amatachaya A, Auvichayapat N, Patjanasoontorn N, . Effect of anodal transcranial direct current stimulation on autism: a randomized double-blind crossover trial. Behav Neurol. 2014;2014:173073. doi: 10.1155/2014/173073.25530675
2169 Amodeo DA, Yi J, Sweeney JA, . Oxotremorine treatment reduces repetitive behaviors in BTBR T+ tf/J mice. Front Synaptic Neurosci. 2014;6:17. doi: 10.3389/fnsyn.2014.00017. X-125165445
2170 Amoros E, Tzvetkovitch A. [Aquatic therapy for children with autism]. Soins Pediatr Pueric. 2014 Jan–Feb(276):29–30. X-1
2171 Andersen AB, Ehrenstein V, Erichsen R, . Autism spectrum disorders in children of parents with inflammatory bowel disease - a nationwide cohort study in Denmark. Clin Exp Gastroenterol. 2014;7:105–10. doi: 10.2147/ceg.s59360. X-124855384
2172 Anderson DK, Liang JW, Lord C. Predicting young adult outcome among more and less cognitively able individuals with autism spectrum disorders. J Child Psychol Psychiatry. 2014 May;55(5):485–94. doi: 10.1111/jcpp.12178. X-124313878
2173 Anderson G, Maes M. Redox Regulation and the Autistic Spectrum: Role of Tryptophan Catabolites, Immuno-inflammation, Autoimmunity and the Amygdala. Curr Neuropharmacol. 2014 Mar;12(2):148–67. doi: 10.2174/1570159x11666131120223757. X-124669209
2174 Anderson KA, Shattuck PT, Cooper BP, . Prevalence and correlates of postsecondary residential status among young adults with an autism spectrum disorder. Autism. 2014 Jul;18(5):562–70. doi: 10.1177/1362361313481860. X-123996904
2175 Aoki Y, Yahata N, Watanabe T, . Oxytocin improves behavioural and neural deficits in inferring others’ social emotions in autism. Brain. 2014 Nov;137(Pt 11):3073–86. doi: 10.1093/brain/awu231. X-125149412
2176 Armus M, Costa JJ. [Between the exaggerated and the exasperated clinic. Bridges, differences and rupture in child and youth mental care]. Vertex. 2014 Jul–Aug;25(116):279–89. X-125546643
2177 Ashburner J, Rodger S, Ziviani J, . Occupational therapy services for people with autism spectrum disorders: current state of play, use of evidence and future learning priorities. Aust Occup Ther J. 2014 Apr;61(2):110–20. doi: 10.1111/1440-1630.12083. X-124118044
2178 Ashburner JK, Rodger SA, Ziviani JM, . Optimizing participation of children with autism spectrum disorder experiencing sensory challenges: a clinical reasoning framework. Can J Occup Ther. 2014 Feb;81(1):29–38. X-124783486
2179 Ashburner JK, Rodger SA, Ziviani JM, . Optimizing participation of children with autism spectrum disorder experiencing sensory challenges: A clinical reasoning framework: Optimiser la participation des enfants atteints d’un trouble du spectre autistique ayant des troubles. Canadian Journal of Occupational Therapy. 2014;81(1):29–38 10p. doi: 10.1177/0008417413520440. Language: English. Entry Date: 20140312. Revision Date: 20150820. Publication Type: Journal Article. X-1
2180 Ashburner JK, Rodger SA, Ziviani JM, . Comment on: ‘An intervention for sensory difficulties in children with autism: A randomized trial’ by Schaaf, et al. (2013). Journal of Autism and Developmental Disorders. 2014 2015-02-24;44(6):1486–8. doi: 10.1136/bmj.f3755. 10.1007/s10803-013-1983-8. http://dx.doi.org/10.1007/s10803-014-2083-0; 2014-09007-001. X-1, X-224610043
2181 Ashwin C, Chapman E, Howells J, . Enhanced olfactory sensitivity in autism spectrum conditions. Mol Autism. 2014;5:53. doi: 10.1186/2040-2392-5-53. X-125908951
2182 Ayyangar KM, Rani RA, Kumar A, . Monte Carlo study of MLC fields for cobalt therapy machine. J Med Phys. 2014 Apr;39(2):71–84. doi: 10.4103/0971-6203.131279. X-124872604
2183 Azuma H, Mohri I, Tachibana M, . [An analysis of the developmental trajectory of children with autism spectrum disorders]. No To Hattatsu. 2014 Nov;46(6):429–37. X-125558586
2184 Bacchelli E, Ceroni F, Pinto D, . A CTNNA3 compound heterozygous deletion implicates a role for alphaT-catenin in susceptibility to autism spectrum disorder. J Neurodev Disord. 2014;6(1):17. doi: 10.1186/1866-1955-6-17. X-125050139
2185 Bacon EC, Dufek S, Schreibman L, . Measuring outcome in an early intervention program for toddlers with autism spectrum disorder: use of a curriculum-based assessment. Autism Res Treat. 2014;2014:964704. doi: 10.1155/2014/964704. X-1, X-324711926
2186 Bagatell NJ, Cram M, Alvarez CG, . Routines of families with adolescents with autistic disorders: a comparison study. Can J Occup Ther. 2014 Feb;81(1):62–7. X-124783489
2187 Baghdadli A, Pry R, Michelon C, . Impact of autism in adolescents on parental quality of life. Qual Life Res. 2014 Aug;23(6):1859–68. doi: 10.1007/s11136-014-0635-6. X-124504623
2188 Baker SM, Milivojevich A, Kraycar T, . Secular trend of sex ratio and symptom patterns among children with autism spectrum disorders. Glob Adv Health Med. 2014 May;3(3):92–101. doi: 10.7453/gahmj.2014.028. X-124944876
2189 Bakri MH, Ismail EA, Elsedfy GO, . Behavioral impact of sickle cell disease in young children with repeated hospitalization. Saudi J Anaesth. 2014 Oct;8(4):504–9. doi: 10.4103/1658-354x.140867. X-125422609
2190 Balan S, Iwayama Y, Maekawa M, . Exon resequencing of H3K9 methyltransferase complex genes, EHMT1, EHTM2 and WIZ, in Japanese autism subjects. Mol Autism. 2014;5(1):49. doi: 10.1186/2040-2392-5-49. X-125400900
2191 Bales KL, Solomon M, Jacob S, . Long-term exposure to intranasal oxytocin in a mouse autism model. Transl Psychiatry. 2014;4:e480. doi: 10.1038/tp.2014.117. X-125386957
2192 Bambini-Junior V, Zanatta G, Della Flora Nunes G, . Resveratrol prevents social deficits in animal model of autism induced by valproic acid. Neurosci Lett. 2014 Nov 7;583:176–81. doi: 10.1016/j.neulet.2014.09.039. X-125263788
2193 Banerjee A, Engineer CT, Sauls BL, . Abnormal emotional learning in a rat model of autism exposed to valproic acid in utero. Front Behav Neurosci. 2014;8:387. doi: 10.3389/fnbeh.2014.00387. X-125429264
2194 Barbalat G, Leboyer M, Zalla T. A specific impairment in cognitive control in individuals with high-functioning autism. J Psychiatr Res. 2014 Nov;58:26–35. doi: 10.1016/j.jpsychires.2014.07.013. X-125106070
2195 Barnard-Brak L, Thompson S, Wei T, . Assistive technology as a predictor of general or alternate assessment among elementary-aged students with autism spectrum disorders. Assist Technol. 2014 Summer;26(2):81–7. doi: 10.1080/10400435.2013.833557. X-125112052
2196 Barry S, O’Sullivan EA, Toumba KJ. Barriers to dental care for children with autism spectrum disorder. Eur Arch Paediatr Dent. 2014 Apr;15(2):127–34. doi: 10.1007/s40368-013-0075-y. X-123943360
2197 Barvalia P. Homeopathic Management of Autism Spectrum Disorder: Illustrative Cases. Homoeopathic Heritage. 2014;39(12):35–42 8p. Language: English. Entry Date: 20140425. Revision Date: 20150712. Publication Type: Journal Article. X-1
2198 Baxter P. Valproate and folic acid in pregnancy: associations with autism. Developmental Medicine & Child Neurology. 2014;56(7):604- 1p. doi: 10.1111/dmcn.12498. Language: English. Entry Date: 20140815. Revision Date: 20150710. Publication Type: Journal Article. X-124924417
2199 Bebko JM, Schroeder JH, Weiss JA. The McGurk effect in children with autism and Asperger syndrome. Autism Res. 2014 Feb;7(1):50–9. doi: 10.1002/aur.1343. X-124136870
2200 Becker JA, Clesse D, Spiegelhalter C, . Autistic-like syndrome in mu opioid receptor null mice is relieved by facilitated mGluR4 activity. Neuropsychopharmacology. 2014 Aug;39(9):2049–60. doi: 10.1038/npp.2014.59. X-124619243
2201 Bedford R, Pickles A, Gliga T, . Additive effects of social and non-social attention during infancy relate to later autism spectrum disorder. Dev Sci. 2014 Jul;17(4):612–20. X-125089324
2202 Bekele E, Crittendon JA, Swanson A, . Pilot clinical application of an adaptive robotic system for young children with autism. Autism. 2014 Jul;18(5):598–608. doi: 10.1177/1362361313479454. X-1, X-324104517
2203 Bekhet AK. Self-assessed health in caregivers of persons with autism spectrum disorder: associations with depressive symptoms, positive cognitions, resourcefulness, and well-being. Perspect Psychiatr Care. 2014 Jul;50(3):210–7. doi: 10.1111/ppc.12046. X-124206628
2204 Bekhet AK, Zauszniewski JA. Psychometric properties of the resourcefulness scale among caregivers of persons with autism spectrum disorder. West J Nurs Res. 2014 May;36(5):685–702. doi: 10.1177/0193945913509141. X-124151172
2205 Bellebaum C, Brodmann K, Thoma P. Active and observational reward learning in adults with autism spectrum disorder: relationship with empathy in an atypical sample. Cogn Neuropsychiatry. 2014;19(3):205–25. doi: 10.1080/13546805.2013.823860. X-123998722
2206 Bellusso P, Maumy-Bertrand M, Desnos Y, . Intérêts de la psychothérapie à médiation sensorielle dans le cadre de la prise en charge des troubles de la relation et de la communication chez des enfants autistes sévèrement déficitaires II: Illustration clinique. Neuropsychiatrie de l’Enfance et de l’Adolescence. 2014 2015-12-09;62(2):95–101. doi: http://dx.doi.org/10.1016/j.neurenf.2013.12.009; 2014-07522-006. X-1, X-3, X-4
2207 Ben Said M, Robel L, Messiaen C, . Patient information, consents and privacy protection scheme for an information system dedicated to pervasive developmental disorders. Stud Health Technol Inform. 2014;205:755–9. X-125160288
2208 Bener A, Khattab AO, Al-Dabbagh MM. Is high prevalence of Vitamin D deficiency evidence for autism disorder?: In a highly endogamous population. J Pediatr Neurosci. 2014 Sep–Dec;9(3):227–33. doi: 10.4103/1817-1745.147574. X-125624924
2209 Ben-Itzchak E, Watson L, Zachor D. Cognitive Ability is Associated with Different Outcome Trajectories in Autism Spectrum Disorders. Journal of Autism & Developmental Disorders. 2014;44(9):2221–9 9p. doi: 10.1007/s10803-014-2091-0. Language: English. Entry Date: 20140818. Revision Date: 20150901. Publication Type: Journal Article. X-1, X-324710810
2210 Benjamin DP, Mastergeorge AM, McDuffie AS, . Effects of labeling and pointing on object gaze in boys with fragile X syndrome: an eye-tracking study. Res Dev Disabil. 2014 Nov;35(11):2658–72. doi: 10.1016/j.ridd.2014.06.021. X-125062097
2211 Bent S, Hendren RL, Zandi T, . Internet-based, randomized, controlled trial of omega-3 fatty acids for hyperactivity in autism. J Am Acad Child Adolesc Psychiatry. 2014 Jun;53(6):658–66. doi: 10.1016/j.jaac.2014.01.018.24839884
2212 Berger N, Ingersoll B. A Further Investigation of Goal-Directed Intention Understanding in Young Children with Autism Spectrum Disorders. Journal of Autism & Developmental Disorders. 2014;44(12):3204–14 11p. doi: 10.1007/s10803-014-2181-z. Language: English. Entry Date: 20141111. Revision Date: 20151201. Publication Type: Journal Article. X-125001543
2213 Bergstrom R, Najdowski AC, Tarbox J. A systematic replication of teaching children with autism to respond appropriately to lures from strangers. J Appl Behav Anal. 2014 Winter;47(4):861–5. doi: 10.1002/jaba.175. X-1, X-325327476
2214 Blomqvist M, Dahllof G, Bejerot S. Experiences of dental care and dental anxiety in adults with autism spectrum disorder. Autism Res Treat. 2014;2014:238764. doi: 10.1155/2014/238764. X-125530879
2215 Bodner KE, Williams DL, Engelhardt CR, . A Comparison of Measures for Assessing the Level and Nature of Intelligence in Verbal Children and Adults with Autism Spectrum Disorder. Res Autism Spectr Disord. 2014 Nov 1;8(11):1434–42. doi: 10.1016/j.rasd.2014.07.015. X-125180048
2216 Boon-Yasidhi V, Jearnarongrit P, Tulayapichitchock P, . Adverse effects of risperidone in children with autism spectrum disorders in a naturalistic clinical setting at siriraj hospital, Thailand. Psychiatry J. 2014;2014:136158. doi: 10.1155/2014/136158. X-124790986
2217 Bouvet L, Simard-Meilleur AA, Paignon A, . Auditory local bias and reduced global interference in autism. Cognition. 2014 Jun;131(3):367–72. doi: 10.1016/j.cognition.2014.02.006. X-124637103
2218 Boyd BA, Hume K, McBee MT, . Comparative efficacy of LEAP, TEACCH and non-model-specific special education programs for preschoolers with autism spectrum disorders. J Autism Dev Disord. 2014 Feb;44(2):366–80. doi: 10.1007/s10803-013-1877-9. X-123812661
2219 Boyle P, Haines D, Lovelock L, . Home safety for children with autistic spectrum disorder: local authority occupational therapy intervention. British Journal of Occupational Therapy (College of Occupational Therapists Limited). 2014;77(5):243–50 8p. doi: 10.4276/030802214X13990455043485. Language: English. Entry Date: 20140509. Revision Date: 20150820. Publication Type: Journal Article. X-1
2220 Bradstreet JJ, Sych N, Antonucci N, . Efficacy of fetal stem cell transplantation in autism spectrum disorders: an open-labeled pilot study. Cell Transplant. 2014;23(Suppl 1):S105–12. doi: 10.3727/096368914x684916. X-325302490
2221 Braun JM, Froehlich T, Kalkbrenner A, . Brief report: are autistic-behaviors in children related to prenatal vitamin use and maternal whole blood folate concentrations? J Autism Dev Disord. 2014 Oct;44(10):2602–7. doi: 10.1007/s10803-014-2114-x. X-124710813
2222 Brisson J, Martel K, Serres J, . Acoustic analysis of oral productions of infants later diagnosed with autism and their mother. Infant Ment Health J. 2014 May–Jun;35(3):285–95. doi: 10.1002/imhj.21442. X-125798482
2223 Broder-Fingert S, Brazauskas K, Lindgren K, . Prevalence of overweight and obesity in a large clinical sample of children with autism. Acad Pediatr. 2014 Jul–Aug;14(4):408–14. doi: 10.1016/j.acap.2014.04.004. X-124976353
2224 Broder-Fingert S, Ferrone CF, Giauque A, . Residents’ knowledge and comfort with caring for children with autism spectrum disorder. Clin Pediatr (Phila). 2014 Dec;53(14):1390–2. doi: 10.1177/0009922814526982. X-124647693
2225 Brodeur DA, Gordon Green C, Flores H, . Time estimation among low-functioning individuals with autism spectrum disorders: evidence of poor sensitivity to variability of short durations. Autism Res. 2014 Apr;7(2):237–44. doi: 10.1002/aur.1364. X-124574256
2226 Brodhead MT, Higbee TS, Pollard JS, . The use of linked activity schedules to teach children with autism to play hide-and-seek. J Appl Behav Anal. 2014 Fall;47(3):645–50. doi: 10.1002/jaba.145. X-3, X-424905481
2227 Brodkin J, Frank D, Grippo R, . Validation and implementation of a novel high-throughput behavioral phenotyping instrument for mice. J Neurosci Methods. 2014 Mar 15;224:48–57. doi: 10.1016/j.jneumeth.2013.12.010. X-124384067
2228 Brown A, Crowe L, Andresen BS, . Neurodevelopmental profiles of children with very long chain acyl-CoA dehydrogenase deficiency diagnosed by newborn screening. Mol Genet Metab. 2014 Dec;113(4):278–82. doi: 10.1016/j.ymgme.2014.10.005. X-125456746
2229 Brown AB, Elder JH. Communication in autism spectrum disorder: a guide for pediatric nurses. Pediatr Nurs. 2014 Sep–Oct;40(5):219–25. X-125929112
2230 Brown CM, Austin DW, Busija L. Observable essential fatty acid deficiency markers and autism spectrum disorder. Breastfeed Rev. 2014 Jul;22(2):21–6. X-1
2231 Bryson SA, Ostmeyer KF. Increasing the effectiveness of community mental health center social skills groups for children with autism spectrum disorder: a training and consultation example. Adm Policy Ment Health. 2014 Nov;41(6):808–21. doi: 10.1007/s10488-013-0533-1. X-124389835
2232 Buck TR, Viskochil J, Farley M, . Psychiatric comorbidity and medication use in adults with autism spectrum disorder. J Autism Dev Disord. 2014 Dec;44(12):3063–71. doi: 10.1007/s10803-014-2170-2. X-124958436
2233 Budday S, Raybaud C, Kuhl E. A mechanical model predicts morphological abnormalities in the developing human brain. Sci Rep. 2014;4:5644. doi: 10.1038/srep05644. X-125008163
2234 Burgess S, Cimera RE. Employment outcomes of transition-aged adults with autism spectrum disorders: a state of the States report. Am J Intellect Dev Disabil. 2014 Jan;119(1):64–83. doi: 10.1352/1944-7558-119.1.64. X-124450322
2235 Burgoyne L, Dowling L, Fitzgerald A, . Parents’ perspectives on the value of assistance dogs for children with autism spectrum disorder: a cross-sectional study. BMJ Open. 2014;4(6):e004786. doi: 10.1136/bmjopen-2014-004786. X-1
2236 Burke A. Zen shiatsu: a longitudinal case study measuring stress reduction in a child with autism spectrum disorder. Int J Ther Massage Bodywork. 2014 Dec;7(4):23–8. X-1, X-3, X-425452821
2237 Butrimaviciute R, Grieve A. Carers’ experiences of being exposed to challenging behaviour in services for autism spectrum disorders. Autism. 2014 Nov;18(8):882–90. doi: 10.1177/1362361313508022. X-124142795
2238 Camacho J, Jones K, Miller E, . Embryonic intraventricular exposure to autism-specific maternal autoantibodies produces alterations in autistic-like stereotypical behaviors in offspring mice. Behav Brain Res. 2014 Jun 1;266:46–51. doi: 10.1016/j.bbr.2014.02.045. X-124613242
2239 Campbell DJ, Chang J, Chawarska K. Early generalized overgrowth in autism spectrum disorder: prevalence rates, gender effects, and clinical outcomes. J Am Acad Child Adolesc Psychiatry. 2014 Oct;53(10):1063–73.e5. doi: 10.1016/j.jaac.2014.07.008. X-125245350
2240 Campillo C, Herrera G, Remirez de Ganuza C, . Using Tic-Tac software to reduce anxiety-related behaviour in adults with autism and learning difficulties during waiting periods: a pilot study. Autism. 2014 Apr;18(3):264–71. doi: 10.1177/1362361312472067. X-124092839
2241 Canal-Bedia R, Garcia-Primo P, Santos-Borbujo J, . [Screening and early care programmes in children with autism spectrum disorders]. Rev Neurol. 2014 Feb 24;58(Suppl 1):S123–7. X-1, X-225252658
2242 Carroll D, Hallett V, McDougle CJ, . Examination of aggression and self-injury in children with autism spectrum disorders and serious behavioral problems. Child Adolesc Psychiatr Clin N Am. 2014 Jan;23(1):57–72. doi: 10.1016/j.chc.2013.08.002. X-1, X-2, X-324231167
2243 Cassidy S, Bradley P, Robinson J, . Suicidal ideation and suicide plans or attempts in adults with Asperger’s syndrome attending a specialist diagnostic clinic: a clinical cohort study. Lancet Psychiatry. 2014 Jul;1(2):142–7. doi: 10.1016/s2215-0366(14)70248-2. X-126360578
2244 Cattelan C. «Essere un bambino in carne ed ossa»… «diventare come tutti gli altri». Rivista di Psicoanalisi. 2014 2015-02-24;60(3):641–55; 2014-56459-022. X-1, X-2
2245 Chan GF, Lai KY, Luk ES, . Clinical utility of the Chinese Strengths and Weaknesses of ADHD-Symptoms and Normal-Behaviors questionnaire (SWAN) when compared with DISC-IV. Neuropsychiatr Dis Treat. 2014;10:1533–42. doi: 10.2147/ndt.s65879. X-125187717
2246 Chan JS, Naumer MJ. Explaining autism spectrum disorders: Central coherence vs. predictive coding theories. Journal of Neurophysiology. 2014 2015-12-09;112(11):2669–71. doi: http://dx.doi.org/10.1152/jn.00242.2014; 2014-55459-001. X-124872530
2247 Chandler F, Dissanayake C. An investigation of the security of caregiver attachment during middle childhood in children with high-functioning autistic disorder. Autism. 2014 Jul;18(5):485–92. doi: 10.1177/1362361313486205. X-124072664
2248 Chang J, Kueon C, Kim J. Influence of lead on repetitive behavior and dopamine metabolism in a mouse model of iron overload. Toxicol Res. 2014 Dec;30(4):267–76. doi: 10.5487/tr.2014.30.4.267. X-125584146
2249 Chang YC, Laugeson EA, Gantman A, . Predicting treatment success in social skills training for adolescents with autism spectrum disorders: the UCLA Program for the Education and Enrichment of Relational Skills. Autism. 2014 May;18(4):467–70. doi: 10.1177/1362361313478995. X-124108192
2250 Cheak-Zamora NC, Farmer JE, Mayfield WA, . Health care transition services for youth with autism spectrum disorders. Rehabil Psychol. 2014 Aug;59(3):340–8. doi: 10.1037/a0036725. X-125019309
2251 Chen CH, Huang CC, Cheng MC, . Genetic analysis of GABRB3 as a candidate gene of autism spectrum disorders. Mol Autism. 2014;5:36. doi: 10.1186/2040-2392-5-36. X-124999380
2252 Chen CH, Lee IJ, Lin LY. Augmented reality-based self-facial modeling to promote the emotional expression and social skills of adolescents with autism spectrum disorders. Res Dev Disabil. 2014 Nov 8;36c:396–403. doi: 10.1016/j.ridd.2014.10.015. X-1, X-325462499
2253 Chen R, Li C, Xie B, . Clinical and molecular evaluations of siblings with “pure” 11q23.3-qter trisomy or reciprocal monosomy due to a familial translocation t (10;11) (q26;q23.3). Mol Cytogenet. 2014;7(1):101. doi: 10.1186/s13039-014-0101-8. X-125648949
2254 Chen YW, Lin HC, Ng MC, . Activation of mGluR2/3 underlies the effects of N-acetylcystein on amygdala-associated autism-like phenotypes in a valproate-induced rat model of autism. Front Behav Neurosci. 2014;8:219. doi: 10.3389/fnbeh.2014.00219. X-124987341
2255 Chi RP, Snyder AW. Treating autism by targeting the temporal lobes. Med Hypotheses. 2014 Nov;83(5):614–8. doi: 10.1016/j.mehy.2014.08.002. X-125227333
2256 Chilosi AM, Brovedani P, Ferrari AR, . Language regression associated with autistic regression and electroencephalographic (EEG) abnormalities: a prospective study. J Child Neurol. 2014 Jun;29(6):855–9. doi: 10.1177/0883073813482767. X-1, X-3, X-423562946
2257 Chiocchetti AG, Haslinger D, Boesch M, . Protein signatures of oxidative stress response in a patient specific cell line model for autism. Mol Autism. 2014;5(1):10. doi: 10.1186/2040-2392-5-10. X-124512814
2258 Chiu YN, Chou MC, Lee JC, . Determinants of maternal satisfaction with diagnosis disclosure of autism. J Formos Med Assoc. 2014 Aug;113(8):540–8. doi: 10.1016/j.jfma.2012.07.040. X-125037759
2259 Choi CS, Hong M, Kim KC, . Effects of atomoxetine on hyper-locomotive activity of the prenatally valproate-exposed rat offspring. Biomol Ther (Seoul). 2014 Sep;22(5):406–13. doi: 10.4062/biomolther.2014.027. X-125414770
2260 Choi JE, Widjaja F, Careaga M, . Change in plasma cytokine levels during risperidone treatment in children with autism. J Child Adolesc Psychopharmacol. 2014 Dec;24(10):586–9. doi: 10.1089/cap.2013.0108. X-324828014
2261 Chok JT, Koesler B. Distinguishing Obsessive-Compulsive Behavior From Stereotypy: A Preliminary Investigation. Behav Modif. 2014 May;38(3):344–73. doi: 10.1177/0145445513509475. X-124177034
2262 Chomiak T, Hung J, Cihal A, . Auditory-cued sensorimotor task reveals disengagement deficits in rats exposed to the autism-associated teratogen valproic acid. Neuroscience. 2014 May 30;268:212–20. doi: 10.1016/j.neuroscience.2014.02.049. X-124631679
2263 Chuang HC, Huang TN, Hsueh YP. Neuronal excitation upregulates Tbr1, a high-confidence risk gene of autism, mediating Grin2b expression in the adult brain. Front Cell Neurosci. 2014;8:280. doi: 10.3389/fncel.2014.00280. X-125309323
2264 Cidav Z, Marcus SC, Mandell DS. Home- and community-based waivers for children with autism: effects on service use and costs. Intellect Dev Disabil. 2014 Aug;52(4):239–48. doi: 10.1352/1934-9556-52.4.239. X-125061768
2265 Cohen IL, Gardner JM, Karmel BZ, . Rating scale measures are associated with Noldus EthoVision-XT video tracking of behaviors of children on the autism spectrum. Mol Autism. 2014;5(1):15. doi: 10.1186/2040-2392-5-15. X-124548743
2266 Cohen-Silver JH, Muskat B, Ratnapalan S. Autism in the emergency department. Clin Pediatr (Phila). 2014 Oct;53(12):1134–8. doi: 10.1177/0009922814540983. X-125031320
2267 Corbett BA, Swain DM, Coke C, . Improvement in social deficits in autism spectrum disorders using a theatre-based, peer-mediated intervention. Autism Res. 2014 Feb;7(1):4–16. doi: 10.1002/aur.1341. X-1, X-324150989
2268 Corejova A, Janosikova D, Pospisilova V, . Cessation of Nocturnal Enuresis After Intervention with Methylcobalamin in an 18-Year-Old Patient with Autism. J Child Adolesc Psychopharmacol. 2014 Oct 17 doi: 10.1089/cap.2014.0023. X-1, X-4
2269 Couper L, van der Meer L, Schafer MC, . Comparing acquisition of and preference for manual signs, picture exchange, and speech-generating devices in nine children with autism spectrum disorder. Dev Neurorehabil. 2014 Apr;17(2):99–109. doi: 10.3109/17518423.2013.870244. X-3, X-424392652
2270 Crewther DP, Crewther DP. Peripheral global neglect in high vs. low autistic tendency. Front Psychol. 2014;5:284. doi: 10.3389/fpsyg.2014.00284. X-124772100
2271 Crider A, Pandya CD, Peter D, . Ubiquitin-proteasome dependent degradation of GABAAalpha1 in autism spectrum disorder. Mol Autism. 2014;5:45. doi: 10.1186/2040-2392-5-45. X-125392730
2272 Crider A, Thakkar R, Ahmed AO, . Dysregulation of estrogen receptor beta (ERbeta), aromatase (CYP19A1), and ER co-activators in the middle frontal gyrus of autism spectrum disorder subjects. Mol Autism. 2014;5(1):46. doi: 10.1186/2040-2392-5-46. X-125221668
2273 Cridland EK, Jones SC, Caputi P, . Being a girl in a boys’ world: investigating the experiences of girls with autism spectrum disorders during adolescence. J Autism Dev Disord. 2014 Jun;44(6):1261–74. doi: 10.1007/s10803-013-1985-6. X-124221816
2274 Cupples L, Ching TYC, Crowe K, . Outcomes of 3-year-old children with hearing loss and different types of additional disabilities. Journal of Deaf Studies and Deaf Education. 2014 2015-12-09;19(1):20–39. doi: http://dx.doi.org/10.1093/deafed/ent039; 2014-01462-002. X-124150488
2275 Dadds MR, MacDonald E, Cauchi A, . Nasal oxytocin for social deficits in childhood autism: a randomized controlled trial. J Autism Dev Disord. 2014 Mar;44(3):521–31. doi: 10.1007/s10803-013-1899-3.23888359
2276 Dahl M, Bergsten C, Hammarberg A, . [Autism spectrum disorders in severe cerebral palsy often discovered late. Retrospective review of 10 years of medical records]. Lakartidningen. 2014 Aug 6–19;111(32–33):1296–8. X-1, X-325221821
2277 Dalsgaard S, Leckman JF, Nielsen HS, . Gender and injuries predict stimulant medication use. J Child Adolesc Psychopharmacol. 2014 Jun;24(5):253–9. doi: 10.1089/cap.2013.0101. X-124813570
2278 Daly B, Nicholls E, Patrick K, . Driving Behaviors in Adults with Autism Spectrum Disorders. Journal of Autism & Developmental Disorders. 2014;44(12):3119–28 10p. doi: 10.1007/s10803-014-2166-y. Language: English. Entry Date: 20141111. Revision Date: 20151201. Publication Type: Journal Article. X-124925544
2279 Damiano CR, Aloi J, Dunlap K, . Association between the oxytocin receptor (OXTR) gene and mesolimbic responses to rewards. Mol Autism. 2014;5(1):7. doi: 10.1186/2040-2392-5-7. X-124485285
2280 Daniel S. [Communicating with a child with autism]. Soins Pediatr Pueric. 2014 Jan–Feb(276):24–5. X-2
2281 Daniels AM, Mandell DS. Explaining differences in age at autism spectrum disorder diagnosis: a critical review. Autism. 2014 Jul;18(5):583–97. doi: 10.1177/1362361313480277. X-123787411
2282 David N, Schultz J, Milne E, . Right Temporoparietal Gray Matter Predicts Accuracy of Social Perception in the Autism Spectrum. Journal of Autism & Developmental Disorders. 2014;44(6):1433–46 14p. doi: 10.1007/s10803-013-2008-3. Language: English. Entry Date: 20140520. Revision Date: 20150710. Publication Type: Journal Article. X-124305776
2283 Davignon MN, Friedlaender E, Cronholm PF, . Parent and provider perspectives on procedural care for children with autism spectrum disorders. J Dev Behav Pediatr. 2014 Apr;35(3):207–15. doi: 10.1097/dbp.0000000000000036. X-124662617
2284 Day-Watkins J, Murray R, Connell JE. Teaching helping to adolescents with autism. J Appl Behav Anal. 2014 Winter;47(4):850–5. doi: 10.1002/jaba.156. X-125168515
2285 de Bruin EI, Graham JH, Louwerse A, . Mild dermatoglyphic deviations in adolescents with autism spectrum disorders and average intellectual abilities as compared to typically developing boys. Autism Res Treat. 2014;2014:968134. doi: 10.1155/2014/968134. X-125478224
2286 de Rezende MU, Hernandez AJ, Camanho GL. The natural history of the anterior knee instability by stress radiography. Acta Ortop Bras. 2014;22(4):183–7. doi: 10.1590/1413-78522014220400940. X-125246846
2287 Degenne-Richard C, Wolff M, Fiard D, . Les spécificités sensorielles des personnes avec autisme de l’enfance à l’âge adulte. A.N.A.E. Approche Neuropsychologique des Apprentissages chez l’Enfant. 2014 2015-12-09;26(1[128]):69–78; 2014-24858-008. X-1, X-2, X-3
2288 Dekker V, Nauta MH, Mulder EJ, . A randomized controlled study of a social skills training for preadolescent children with autism spectrum disorders: generalization of skills by training parents and teachers? BMC Psychiatry. 2014;14:189. doi: 10.1186/1471-244x-14-189. X-124989854
2289 Delfs CH, Conine DE, Frampton SE, . Evaluation of the efficiency of listener and tact instruction for children with autism. J Appl Behav Anal. 2014 Winter;47(4):793–809. doi: 10.1002/jaba.166. X-3, X-425324150
2290 D’Elia L, Valeri G, Sonnino F, . A longitudinal study of the teacch program in different settings: the potential benefits of low intensity intervention in preschool children with autism spectrum disorder. J Autism Dev Disord. 2014 Mar;44(3):615–26. doi: 10.1007/s10803-013-1911-y. X-123949000
2291 Demoz Z, Legesse B, Teklay G, . Medication adherence and its determinants among psychiatric patients in an Ethiopian referral hospital. Patient Prefer Adherence. 2014;8:1329–35. doi: 10.2147/ppa.s69702. X-125284991
2292 Denmark T, Atkinson J, Campbell R, . How do typically developing deaf children and deaf children with autism spectrum disorder use the face when comprehending emotional facial expressions in British sign language? J Autism Dev Disord. 2014 Oct;44(10):2584–92. doi: 10.1007/s10803-014-2130-x. X-124803370
2293 Dere E, Dahm L, Lu D, . Heterozygous ambra1 deficiency in mice: a genetic trait with autism-like behavior restricted to the female gender. Front Behav Neurosci. 2014;8:181. doi: 10.3389/fnbeh.2014.00181. X-124904333
2294 Dickinson K, Place M. A Randomised Control Trial of the Impact of a Computer-Based Activity Programme upon the Fitness of Children with Autism. Autism Res Treat. 2014;2014:419653. doi: 10.1155/2014/419653. X-125400946
2295 Dickstein-Fischer L, Fischer GS. Combining psychological and engineering approaches to utilizing social robots with children with Autism. Conf Proc IEEE Eng Med Biol Soc. 2014 Aug;2014:792–5. doi: 10.1109/embc.2014.6943710. X-125570078
2296 Diez-Juan M, Schneider A, Phillips T, . Parent-delivered touchscreen intervention for children with fragile X syndrome. Intractable Rare Dis Res. 2014 Nov;3(4):166–77. doi: 10.5582/irdr.2014.01026. X-1, X-325606367
2297 Domes G, Kumbier E, Heinrichs M, . Oxytocin promotes facial emotion recognition and amygdala reactivity in adults with asperger syndrome. Neuropsychopharmacology. 2014 Feb;39(3):698–706. doi: 10.1038/npp.2013.254. X-124067301
2298 Donaldson AL, Stahmer AC. Team collaboration: the use of behavior principles for serving students with ASD. Lang Speech Hear Serv Sch. 2014 Oct;45(4):261–76. doi: 10.1044/2014_lshss-14-0038. X-125091620
2299 Donato C, Shane HC, Hemsley B. Exploring the feasibility of the visual language in autism program for children in an early intervention group setting: views of parents, educators, and health professionals. Dev Neurorehabil. 2014 Apr;17(2):115–24. doi: 10.3109/17518423.2014.880526. X-124564265
2300 Downs R, Perna J, Vitelli A, . Model-based hypothesis of gut microbe populations and gut/brain barrier permeabilities in the development of regressive autism. Med Hypotheses. 2014 Dec;83(6):649–55. doi: 10.1016/j.mehy.2014.09.005. X-125288537
2301 Drahota A, Stadnick N, Brookman-Frazee L. Therapist perspectives on training in a package of evidence-based practice strategies for children with autism spectrum disorders served in community mental health clinics. Adm Policy Ment Health. 2014 Jan;41(1):114–25. doi: 10.1007/s10488-012-0441-9. X-1, X-3, X-423086499
2302 Duan G, Yao M, Ma Y, . Perinatal and background risk factors for childhood autism in central China. Psychiatry Res. 2014 Dec 15;220(1–2):410–7. doi: 10.1016/j.psychres.2014.05.057. X-125085792
2303 Dudova I, Markova D, Kasparova M, . Comparison of three screening tests for autism in preterm children with birth weights less than 1,500 grams. Neuropsychiatr Dis Treat. 2014;10:2201–8. doi: 10.2147/ndt.s72921. X-125484588
2304 Duffy FH, Shankardass A, McAnulty GB, . Corticosteroid therapy in regressive autism: a retrospective study of effects on the Frequency Modulated Auditory Evoked Response (FMAER), language, and behavior. BMC Neurol. 2014;14:70. doi: 10.1186/1471-2377-14-70.24885033
2305 Duzyj CM, Paidas MJ, Jebailey L, . PreImplantation factor (PIF*) promotes embryotrophic and neuroprotective decidual genes: effect negated by epidermal growth factor. J Neurodev Disord. 2014;6(1):36. doi: 10.1186/1866-1955-6-36. X-126085845
2306 Dvash J, Shamay-Tsoory SG. Theory of Mind and Empathy as Multidimensional Constructs. Topics in Language Disorders. 2014;34(4):282–95 14p. doi: 10.1097/TLD.0000000000000040. Language: English. Entry Date: 20141124. Revision Date: 20150712. Publication Type: Journal Article. X-1
2307 Dykens EM, Fisher MH, Taylor JL, . Reducing distress in mothers of children with autism and other disabilities: a randomized trial. Pediatrics. 2014 Aug;134(2):e454–63. doi: 10.1542/peds.2013-3164. X-125049350
2308 Eapen V, Crncec R, Walter A, . Conceptualisation and development of a quality of life measure for parents of children with autism spectrum disorder. Autism Res Treat. 2014;2014:160783. doi: 10.1155/2014/160783. X-124778873
2309 Eden KE, de Vries PJ, Moss J, . Self-injury and aggression in tuberous sclerosis complex: cross syndrome comparison and associated risk markers. J Neurodev Disord. 2014;6(1):10. doi: 10.1186/1866-1955-6-10. X-124822087
2310 Edmonson C, Ziats MN, Rennert OM. Altered glial marker expression in autistic post-mortem prefrontal cortex and cerebellum. Mol Autism. 2014;5(1):3. doi: 10.1186/2040-2392-5-3. X-124410870
2311 Eisenstein M. Public health: An injection of trust. Nature. 2014 Mar 6;507(7490):S17–9. X-124611174
2312 Eisinger BE, Driessen TM, Zhao C, . Medial prefrontal cortex: genes linked to bipolar disorder and schizophrenia have altered expression in the highly social maternal phenotype. Front Behav Neurosci. 2014;8:110. doi: 10.3389/fnbeh.2014.00110. X-124765068
2313 El Marroun H, White T, Verhulst F, . Maternal use of antidepressant or anxiolytic medication during pregnancy and childhood neurodevelopmental outcomes: a systematic review. European Child & Adolescent Psychiatry. 2014;23(10):973–92 20p. doi: 10.1007/s00787-014-0558-3. Language: English. Entry Date: 20141010. Revision Date: 20151001. Publication Type: Journal Article. X-1, X-224863148
2314 El-Ansary A, Al-Ayadhi L. GABAergic/glutamatergic imbalance relative to excessive neuroinflammation in autism spectrum disorders. J Neuroinflammation. 2014;11:189. doi: 10.1186/s12974-014-0189-0. X-125407263
2315 Elberling H, Linneberg A, Olsen EM, . Infancy predictors of hyperkinetic and pervasive developmental disorders at ages 5–7 years: results from the Copenhagen Child Cohort CCC2000. J Child Psychol Psychiatry. 2014 Dec;55(12):1328–35. doi: 10.1111/jcpp.12256. X-124889385
2316 Elder GJ, Taylor JP. Transcranial magnetic stimulation and transcranial direct current stimulation: treatments for cognitive and neuropsychiatric symptoms in the neurodegenerative dementias? Alzheimers Res Ther. 2014;6(9):74. doi: 10.1186/s13195-014-0074-1. X-125478032
2317 Eldridge J, Lane AE, Belkin M, . Robust features for the automatic identification of autism spectrum disorder in children. J Neurodev Disord. 2014;6(1):12. doi: 10.1186/1866-1955-6-12. X-124936212
2318 Elison JT, Wolff JJ, Reznick JS, . Repetitive behavior in 12-month-olds later classified with autism spectrum disorder. J Am Acad Child Adolesc Psychiatry. 2014 Nov;53(11):1216–24. doi: 10.1016/j.jaac.2014.08.004. X-125440311
2319 Engineer CT, Centanni TM, Im KW, . Degraded auditory processing in a rat model of autism limits the speech representation in non-primary auditory cortex. Dev Neurobiol. 2014 Oct;74(10):972–86. doi: 10.1002/dneu.22175. X-124639033
2320 Engineer CT, Centanni TM, Im KW, . Speech sound discrimination training improves auditory cortex responses in a rat model of autism. Front Syst Neurosci. 2014;8:137. doi: 10.3389/fnsys.2014.00137. X-125140133
2321 Enloe KA, Rapp JT. Effects of Noncontingent Social Interaction on Immediate and Subsequent Engagement in Vocal and Motor Stereotypy in Children With Autism. Behav Modif. 2014 May;38(3):374–91. doi: 10.1177/0145445513514081. X-1, X-3, X-424302122
2322 Enticott PG, Fitzgibbon BM, Kennedy HA, . A double-blind, randomized trial of deep repetitive transcranial magnetic stimulation (rTMS) for autism spectrum disorder. Brain Stimul. 2014 Mar–Apr;7(2):206–11. doi: 10.1016/j.brs.2013.10.004. X-124280031
2323 Erickson CA, Ray B, Maloney B, . Impact of acamprosate on plasma amyloid-beta precursor protein in youth: a pilot analysis in fragile X syndrome-associated and idiopathic autism spectrum disorder suggests a pharmacodynamic protein marker. J Psychiatr Res. 2014 Dec;59:220–8. doi: 10.1016/j.jpsychires.2014.07.011. X-125300441
2324 Erickson CA, Veenstra-Vanderweele JM, Melmed RD, . STX209 (arbaclofen) for autism spectrum disorders: an 8-week open-label study. J Autism Dev Disord. 2014 Apr;44(4):958–64. doi: 10.1007/s10803-013-1963-z. X-324272415
2325 Erickson CA, Wink LK, Early MC, . Brief report: Pilot single-blind placebo lead-in study of acamprosate in youth with autistic disorder. J Autism Dev Disord. 2014 Apr;44(4):981–7. doi: 10.1007/s10803-013-1943-3. X-1, X-3, X-424052275
2326 Estes A, Vismara L, Mercado C, . The impact of parent-delivered intervention on parents of very young children with autism. J Autism Dev Disord. 2014 Feb;44(2):353–65. doi: 10.1007/s10803-013-1874-z. X-123838727
2327 Etzel RA. Foreword: Environmental chemical exposures and autism spectrum disorders: a review of the epidemiological evidence. Curr Probl Pediatr Adolesc Health Care. 2014 Nov;44(10):275–6. doi: 10.1016/j.cppeds.2014.06.002. X-125175915
2328 Eun JJ, Lee HJ, Kim JK. Developmental profiles of preschool children with delayed language development. Korean J Pediatr. 2014 Aug;57(8):363–9. doi: 10.3345/kjp.2014.57.8.363. X-125210524
2329 Evers K, de-Wit L, Hallen R, . Brief Report: Reduced Grouping Interference in Children with ASD: Evidence from a Multiple Object Tracking Task. Journal of Autism & Developmental Disorders. 2014;44(7):1779–87 9p. doi: 10.1007/s10803-013-2031-4. Language: English. Entry Date: 20140620. Revision Date: 20150710. Publication Type: Journal Article. X-124398878
2330 FM C. [“I could see he was not acting like other children”]. Soins Pediatr Pueric. 2014 Jan–Feb(276):34–5. X-1
2331 Faridar A, Jones-Davis D, Rider E, . Mapk/Erk activation in an animal model of social deficits shows a possible link to autism. Mol Autism. 2014;5:57. doi: 10.1186/2040-2392-5-57. X-125874073
2332 Fauquie-Subrin V. [Early educational intervention for autistic children]. Soins Pediatr Pueric. 2014 Jan–Feb(276):28. X-5
2333 Fayemi AK. Diagnosis of autism, abortion and the ethics of childcare in Yoruba culture. Indian J Med Ethics. 2014 Oct–Dec;11(4):245–8. X-125377038
2334 Fayyazi A, Salari E, Khajeh A, . A comparison of risperidone and buspirone for treatment of behavior disorders in children with phenylketonuria. Iran J Child Neurol. 2014 Fall;8(4):33–8. X-125657768
2335 Feimann D, Whalberg E, Costa J. [Interview with Debora Feimann]. Vertex. 2014 Jul–Aug;25(116):299–303. X-125558494
2336 Feinberg E, Augustyn M, Fitzgerald E, . Improving maternal mental health after a child’s diagnosis of autism spectrum disorder: results from a randomized clinical trial. JAMA Pediatr. 2014 Jan;168(1):40–6. doi: 10.1001/jamapediatrics.2013.3445. X-124217336
2337 Fellinger J, Holzinger D. Creating innovative clinical and service models for communication: Institut fuer Sinnes- und Sprachneurologie. J Dev Behav Pediatr. 2014 Feb–Mar;35(2):148–53. doi: 10.1097/dbp.0000000000000019. X-124509058
2338 Feng C, Hackett PD, DeMarco AC, . Oxytocin and vasopressin effects on the neural response to social cooperation are modulated by sex in humans. Brain Imaging Behav. 2014 Nov 22 doi: 10.1007/s11682-014-9333-9. X-1
2339 Fernandez-Jaen A, Cigudosa JC, Martin Fernandez-Mayoralas D, . [Genetics applied to clinical practice in neurodevelopmental disorders]. Rev Neurol. 2014 Feb 24;58(Suppl 1):S65–70. X-125252670
2340 Fernell E, Wilson P, Hadjikhani N, . Screening, intervention and outcome in autism and other developmental disorders: the role of randomized controlled trials. J Autism Dev Disord. 2014 Aug;44(8):2074–6. doi: 10.1007/s10803-014-2070-5. X-124554162
2341 Ferraro FR. No evidence of reaction time slowing in autism spectrum disorder. Autism. 2014 Dec 15 doi: 10.1177/1362361314559986. X-1
2342 Ferreri M. [Pervasive developmental disorders]. Rev Prat. 2014 Apr;64(4):481–6. X-124855782
2343 Fetner M, Cascio CJ, Essick G. Nonverbal patient with autism spectrum disorder and obstructive sleep apnea: use of desensitization to acclimatize to a dental appliance. Pediatr Dent. 2014 Nov–Dec;36(7):499–501. X-125514080
2344 Findling RL, Mankoski R, Timko K, . A randomized controlled trial investigating the safety and efficacy of aripiprazole in the long-term maintenance treatment of pediatric patients with irritability associated with autistic disorder. J Clin Psychiatry. 2014 Jan;75(1):22–30. doi: 10.4088/JCP.13m08500 10.4088/JCP.13m8500.24502859
2345 Fisher WW, Greer BD, Querim AC, . Decreasing excessive functional communication responses while treating destructive behavior using response restriction. Res Dev Disabil. 2014 Nov;35(11):2614–23. doi: 10.1016/j.ridd.2014.06.024. X-1, X-3, X-425036315
2346 Fitzpatrick EM, Lambert L, Whittingham J, . Examination of characteristics and management of children with hearing loss and autism spectrum disorders. Int J Audiol. 2014 Sep;53(9):577–86. doi: 10.3109/14992027.2014.903338. X-1, X-3, X-424832530
2347 Foley AG, Cassidy AW, Regan CM. Pentyl-4-yn-VPA, a histone deacetylase inhibitor, ameliorates deficits in social behavior and cognition in a rodent model of autism spectrum disorders. Eur J Pharmacol. 2014 Mar 15;727:80–6. doi: 10.1016/j.ejphar.2014.01.050. X-124486700
2348 Foti F, Mazzone L, Menghini D, . Learning by observation in children with autism spectrum disorder. Psychol Med. 2014 Aug;44(11):2437–47. doi: 10.1017/s003329171300322x. X-124433947
2349 Frazier JA, McDougle CJ. Special issue on autism spectrum disorders. Introduction Harv Rev Psychiatry. 2014 Mar–Apr;22(2):61–4. doi: 10.1097/hrp.0000000000000028. X-124614761
2350 Freitag CM. [Autism Spectrum Disorder in DSM-5 - concept, validity, and reliability, impact on clinical care and future research]. Z Kinder Jugendpsychiatr Psychother. 2014 May;42(3):185–92. doi: 10.1024/1422-4917/a000288. X-124846867
2351 Freuler AC, Baranek GT, Tashjian C, . Parent reflections of experiences of participating in a randomized controlled trial of a behavioral intervention for infants at risk of autism spectrum disorders. Autism. 2014 Jul;18(5):519–28. doi: 10.1177/1362361313483928. X-1, X-224104508
2352 Fujiwara T, Kawachi I. Are maternal social networks and perceptions of trust associated with suspected autism spectrum disorder in offspring? A population-based study in Japan. PLoS One. 2014;9(7):e101359. doi: 10.1371/journal.pone.0101359. X-124983630
2353 Fulton E, Eapen V, Crncec R, . Reducing maladaptive behaviors in preschool-aged children with autism spectrum disorder using the early start denver model. Front Pediatr. 2014;2:40. doi: 10.3389/fped.2014.00040. X-124847474
2354 Funahashi A, Gruebler A, Aoki T, . Brief report: the smiles of a child with autism spectrum disorder during an animal-assisted activity may facilitate social positive behaviors--quantitative analysis with smile-detecting interface. J Autism Dev Disord. 2014 Mar;44(3):685–93. doi: 10.1007/s10803-013-1898-4. X-3, X-423893100
2355 Funahashi Y, Karashima C, Hoshiyama M. Compensatory postural sway while seated posture during tasks in children with autism spectrum disorder. Occup Ther Int. 2014 Dec;21(4):166–75. doi: 10.1002/oti.1375. X-124956573
2356 Fung LK, Libove RA, Phillips J, . Brief report: an open-label study of the neurosteroid pregnenolone in adults with autism spectrum disorder. J Autism Dev Disord. 2014 Nov;44(11):2971–7. doi: 10.1007/s10803-014-2144-4. X-124849255
2357 Futoo E, Miyawaki D, Goto A, . Sensory hypersensitivity in children with high-functioning pervasive developmental disorder. Osaka City Med J. 2014 Dec;60(2):63–71. X-125803881
2358 Gadow KD, Smith RM, Pinsonneault JK. Serotonin 2A receptor gene (HTR2A) regulatory variants: possible association with severity of depression symptoms in children with autism spectrum disorder. Cogn Behav Neurol. 2014 Jun;27(2):107–16. doi: 10.1097/wnn.0000000000000028. X-124968012
2359 Gandhi RM, Kogan CS, Messier C. 2-Methyl-6-(phenylethynyl) pyridine (MPEP) reverses maze learning and PSD-95 deficits in Fmr1 knock-out mice. Front Cell Neurosci. 2014;8:70. doi: 10.3389/fncel.2014.00070. X-124701200
2360 Garcia-Albea E, Reeve SA, Brothers KJ, . Using audio script fading and multiple-exemplar training to increase vocal interactions in children with autism. J Appl Behav Anal. 2014 Summer;47(2):325–43. doi: 10.1002/jaba.125. X-3, X-424763913
2361 Garcia-Martinez T, Chan JP, Perez-Calatayud J, . Dosimetric characteristics of a new unit for electronic skin brachytherapy. J Contemp Brachytherapy. 2014 Mar;6(1):45–53. doi: 10.5114/jcb.2014.40770. X-124790622
2362 Garg P, Lillystone D, Dossetor D, . An Exploratory Survey for Understanding Perceptions, Knowledge and Educational Needs of General Practitioners (GSs) Regarding Autistic Disorders in New South Wales (NSW), Australia. J Clin Diagn Res. 2014 Jul;8(7):Pc01–9. doi: 10.7860/jcdr/2014/8243.4527. X-1
2363 Gates C. We are what we eat. Eat right to make sure you don’t end up a patient. Jems. 2014 Dec;39(12):66. X-1
2364 Gautam P, Bhatia MS, Rathi A. Intellectual disability and multiple co morbid psychiatric disorders in a child: a case report. J Clin Diagn Res. 2014 Nov;8(11):Wd01–2. doi: 10.7860/jcdr/2014/9336.5110. X-125584292
2365 Gebauer L, Skewes J, Westphael G, . Intact brain processing of musical emotions in autism spectrum disorder, but more cognitive load and arousal in happy vs. sad music. Front Neurosci. 2014;8:192. doi: 10.3389/fnins.2014.00192. X-125076869
2366 Gee BM, Thompson K, St John H. Efficacy of a sound-based intervention with a child with an autism spectrum disorder and auditory sensory over-responsivity. Occup Ther Int. 2014 Mar;21(1):12–20. doi: 10.1002/oti.1359. X-3, X-424532098
2367 George B, Padmam MS, Nair MK, . CDC Kerala 11: Diagnosis of autism among children between 2 and 6 y--comparison of CARS against DSM-IV-TR. Indian J Pediatr. 2014 Dec;81(Suppl 2):S125–8. doi: 10.1007/s12098-014-1625-y. X-125428818
2368 George B, Padmam MS, Nair MK, . CDC Kerala 13: Antenatal, natal and postnatal factors among children (2–6 y) with autism--a case control study. Indian J Pediatr. 2014 Dec;81(Suppl 2):S133–7. doi: 10.1007/s12098-014-1594-1. X-125338492
2369 George B, Padmam MS, Nair MK, . CDC Kerala 14: Early child care practices at home among children (2–6 y) with autism--a case control study. Indian J Pediatr. 2014 Dec;81(Suppl 2):S138–41. doi: 10.1007/s12098-014-1602-5. X-125366290
2370 George B, Padmam MS, Nair MK, . CDC Kerala 12: Socio-demographic factors among children (2–6 y) with autism--a case control study. Indian J Pediatr. 2014 Dec;81(Suppl 2):S129–32. doi: 10.1007/s12098-014-1593-2. X-125366288
2371 Gerber A, Morrow E, Sheinkopf SJ, . The Rhode Island Consortium for Autism Research and Treatment (RI-CART): a new statewide autism collaborative. R I Med J (2013). 2014 May;97(5):31–4. X-1
2372 Germain ND, Chen PF, Plocik AM, . Gene expression analysis of human induced pluripotent stem cell-derived neurons carrying copy number variants of chromosome 15q11-q13.1. Mol Autism. 2014;5:44. doi: 10.1186/2040-2392-5-44. X-125694803
2373 Germani T, Zwaigenbaum L, Bryson S, . Brief report: Assessment of early sensory processing in infants at high-risk of autism spectrum disorder. Journal of Autism and Developmental Disorders. 2014 2015-12-09;44(12):3264–70. doi: 10.1007/s10803-012-1612-y. doi: 10.1007/s10803-013-1876-x. doi: 10.1007/s10802-008-9258-0. http://dx.doi.org/10.1007/s10803-014-2175-x; 2014-27047-001. X-124970108
2374 Ghaeli P, Nikvarz N, Alaghband-Rad J, . Effects of risperidone on core symptoms of autistic disorder based on childhood autism rating scale: an open label study. Indian J Psychol Med. 2014 Jan;36(1):66–70. doi: 10.4103/0253-7176.127254. X-324701014
2375 Ghanizadeh A, Sahraeizadeh A, Berk M. A head-to-head comparison of aripiprazole and risperidone for safety and treating autistic disorders, a randomized double blind clinical trial. Child Psychiatry Hum Dev. 2014;45(2):185–92. doi: 10.1007/s10578-013-0390-x.23801256
2376 Giacobini M, Medin E, Ahnemark E, . Prevalence, Patient Characteristics, and Pharmacological Treatment of Children, Adolescents, and Adults Diagnosed With ADHD in Sweden. J Atten Disord. 2014 Nov 5 doi: 10.1177/1087054714554617. X-1
2377 Giarelli E, Nocera R, Turchi R, . Sensory stimuli as obstacles to emergency care for children with autism spectrum disorder. Adv Emerg Nurs J. 2014 Apr–Jun;36(2):145–63. doi: 10.1097/tme.0000000000000013. X-124785668
2378 Gidaya NB, Lee BK, Burstyn I, . In utero exposure to selective serotonin reuptake inhibitors and risk for autism spectrum disorder. J Autism Dev Disord. 2014 Oct;44(10):2558–67. doi: 10.1007/s10803-014-2128-4. X-124803368
2379 Gidley Larson J, Suchy Y. Does Language Guide Behavior in Children with Autism? Journal of Autism & Developmental Disorders. 2014;44(9):2147–61 15p. doi: 10.1007/s10803-014-2089-7. Language: English. Entry Date: 20140818. Revision Date: 20150901. Publication Type: Journal Article. X-1, X-324710809
2380 Gigliucci V, Leonzino M, Busnelli M, . Region specific up-regulation of oxytocin receptors in the opioid oprm1 (−/−) mouse model of autism. Front Pediatr. 2014;2:91. doi: 10.3389/fped.2014.00091. X-125225634
2381 Gillberg C. [Not Available]. Lakartidningen. 2014 Sep 24–30;111(39). X-1
2382 Gillespie-Smith K, Riby DM, Hancock PJ, . Children with autism spectrum disorder (ASD) attend typically to faces and objects presented within their picture communication systems. J Intellect Disabil Res. 2014 May;58(5):459–70. doi: 10.1111/jir.12043. X-1, X-323600472
2383 Gkogkas CG, Khoutorsky A, Cao R, . Pharmacogenetic inhibition of eIF4E-dependent Mmp9 mRNA translation reverses fragile X syndrome-like phenotypes. Cell Rep. 2014 Dec 11;9(5):1742–55. doi: 10.1016/j.celrep.2014.10.064. X-125466251
2384 Goldman SE, Adkins KW, Calcutt MW, . Melatonin in children with autism spectrum disorders: endogenous and pharmacokinetic profiles in relation to sleep. J Autism Dev Disord. 2014 Oct;44(10):2525–35. doi: 10.1007/s10803-014-2123-9. X-1, X-324752680
2385 Goldstein F, Myers K. Telemental health: a new collaboration for pediatricians and child psychiatrists. Pediatr Ann. 2014 Feb;43(2):79–84. doi: 10.3928/00904481-20140127-12. X-124512157
2386 Gombash SE, Cowley CJ, Fitzgerald JA, . Intravenous AAV9 efficiently transduces myenteric neurons in neonate and juvenile mice. Front Mol Neurosci. 2014;7:81. doi: 10.3389/fnmol.2014.00081. X-125360081
2387 Gomez C, Lizier JT, Schaum M, . Reduced predictable information in brain signals in autism spectrum disorder. Front Neuroinform. 2014;8:9. doi: 10.3389/fninf.2014.00009. X-124592235
2388 Gonzalez-Gadea ML, Tripicchio P, Rattazzi A, . Inter-individual cognitive variability in children with Asperger’s syndrome. Front Hum Neurosci. 2014;8:575. doi: 10.3389/fnhum.2014.00575. X-125132817
2389 Graber S, Liepelt-Scarfone I, Csoti I, . Post-cueing deficits with maintained cueing benefits in patients with Parkinson’s disease dementia. Front Neurol. 2014;5:236. doi: 10.3389/fneur.2014.00236. X-125477860
2390 Grainger C, Williams D, Lind S. Online Action Monitoring and Memory for Self-Performed Actions in Autism Spectrum Disorder. Journal of Autism & Developmental Disorders. 2014;44(5):1193–206 14p. doi: 10.1007/s10803-013-1987-4. Language: English. Entry Date: 20140414. Revision Date: 20150710. Publication Type: Journal Article. X-124193578
2391 Grant PJ, Joseph LA, Farmer CA, . 12-week, placebo-controlled trial of add-on riluzole in the treatment of childhood-onset obsessive-compulsive disorder. Neuropsychopharmacology. 2014 May;39(6):1453–9. doi: 10.1038/npp.2013.343. X-1, X-424356715
2392 Gray KM, Keating CM, Taffe JR, . Adult outcomes in autism: community inclusion and living skills. J Autism Dev Disord. 2014 Dec;44(12):3006–15. doi: 10.1007/s10803-014-2159-x. X-124915930
2393 Grechanina Iu B, Grechanina E, Beletskaia SV. [Impairments of gastrointestinal tract in autism]. Lik Sprava. 2014 Nov(11):89–93. X-1
2394 Green SA, Carter AS. Predictors and course of daily living skills development in toddlers with autism spectrum disorders. J Autism Dev Disord. 2014 Feb;44(2):256–63. doi: 10.1007/s10803-011-1275-0. X-121598046
2395 Greenslade KJ, Coggins TE. Assessing young children’s intention-reading in authentic communicative contexts: preliminary evidence and clinical utility. Int J Lang Commun Disord. 2014 Jul–Aug;49(4):463–77. doi: 10.1111/1460-6984.12076. X-124684559
2396 Gregory G. Too many questions. Aust J Rural Health. 2014 Apr;22(2):87. doi: 10.1111/ajr.12111. X-124731207
2397 Groskreutz NC, Groskreutz MP, Bloom SE, . Generalization of negatively reinforced mands in children with autism. J Appl Behav Anal. 2014 Fall;47(3):560–79. doi: 10.1002/jaba.151. X-3, X-425087550
2398 Grow LL, Kodak T, Carr JE. A comparison of methods for teaching receptive labeling to children with autism spectrum disorders: a systematic replication. J Appl Behav Anal. 2014 Fall;47(3):600–5. doi: 10.1002/jaba.141. X-1, X-3, X-424902513
2399 Gu Y, Chen J, Lu Y, . Integrative Frequency Power of EEG Correlates with Progression of Mild Cognitive Impairment to Dementia in Parkinson’s Disease. Clin EEG Neurosci. 2014 Dec 16 doi: 10.1177/1550059414543796. X-1
2400 Gulsrud AC, Hellemann GS, Freeman SF, . Two to ten years: developmental trajectories of joint attention in children with ASD who received targeted social communication interventions. Autism Res. 2014 Apr;7(2):207–15. doi: 10.1002/aur.1360. X-1, X-324550145
2401 Gunby KV, Rapp JT. The use of behavioral skills training and in situ feedback to protect children with autism from abduction lures. J Appl Behav Anal. 2014 Winter;47(4):856–60. doi: 10.1002/jaba.173. X-3, X-425311885
2402 Gustafsson P, Kerekes N, Anckarsater H, . Motor function and perception in children with neuropsychiatric and conduct problems: results from a population based twin study. J Neurodev Disord. 2014;6(1):11. doi: 10.1186/1866-1955-6-11. X-124872861
2403 Gutman SA, Raphael-Greenfield EI, Kerr L, . Using Motor-Based Role-Play to Enhance Social Skills in a Nonverbal Adolescent With High Functioning Autism: A Case Report. Occupational Therapy in Mental Health. 2014;30(1):12–25 14p. doi: 10.1080/0164212X.2014.878235. Language: English. Entry Date: 20140320. Revision Date: 20150819. Publication Type: Journal Article. X-1, X-3, X-4
2404 Gvozdjakova A, Kucharska J, Ostatnikova D, . Ubiquinol improves symptoms in children with autism. Oxid Med Cell Longev. 2014;2014:798957. doi: 10.1155/2014/798957. X-324707344
2405 Ha VS, Whittaker A, Whittaker M, . Living with autism spectrum disorder in Hanoi, Vietnam. Soc Sci Med. 2014 Nov;120:278–85. doi: 10.1016/j.socscimed.2014.09.038. X-125262315
2406 Halepoto DM, Al-Ayadhi LY, Salam AA. Therapeutic use of hyperbaric oxygen therapy for children with autism spectrum disorder. J Coll Physicians Surg Pak. 2014 Jul;24(7):508–14. X-1, X-2, X-325052976
2407 Halls G, Cooper PJ, Creswell C. Social communication deficits: Specific associations with Social Anxiety Disorder. J Affect Disord. 2014 Oct 2;172c:38–42. doi: 10.1016/j.jad.2014.09.040. X-1
2408 Han S, Tai C, Jones CJ, . Enhancement of inhibitory neurotransmission by GABAA receptors having alpha2,3-subunits ameliorates behavioral deficits in a mouse model of autism. Neuron. 2014 Mar 19;81(6):1282–9. doi: 10.1016/j.neuron.2014.01.016. X-124656250
2409 Hanaie R, Mohri I, Kagitani-Shimono K, . Abnormal Corpus Callosum Connectivity, Socio-communicative Deficits, and Motor Deficits in Children with Autism Spectrum Disorder: A Diffusion Tensor Imaging Study. Journal of Autism & Developmental Disorders. 2014;44(9):2209–20 12p. doi: 10.1007/s10803-014-2096-8. Language: English. Entry Date: 20140818. Revision Date: 20150901. Publication Type: Journal Article. X-124710811
2410 Hanley GP, Jin CS, Vanselow NR, . Producing meaningful improvements in problem behavior of children with autism via synthesized analyses and treatments. J Appl Behav Anal. 2014 Spring;47(1):16–36. doi: 10.1002/jaba.106. X-3, X-424615474
2411 Hanna M, Jr.. Human vaccines & immunotherapeutics: news. Hum Vaccin Immunother. 2014;10(7):1773–7. doi: 10.4161/hv.36241. X-125424781
2412 Hansen BD, Wadsworth JP, Roberts MR, . Effects of naturalistic instruction on phonological awareness skills of children with intellectual and developmental disabilities. Res Dev Disabil. 2014 Nov;35(11):2790–801. doi: 10.1016/j.ridd.2014.07.011. X-125086428
2413 Hansson O, Hall S, Ohrfelt A, . Levels of cerebrospinal fluid alpha-synuclein oligomers are increased in Parkinson’s disease with dementia and dementia with Lewy bodies compared to Alzheimer’s disease. Alzheimers Res Ther. 2014;6(3):25. doi: 10.1186/alzrt255. X-124987465
2414 Harfterkamp M, Buitelaar JK, Minderaa RB, . Atomoxetine in autism spectrum disorder: no effects on social functioning; some beneficial effects on stereotyped behaviors, inappropriate speech, and fear of change. J Child Adolesc Psychopharmacol. 2014 Nov;24(9):481–5. doi: 10.1089/cap.2014.0026.25369243
2415 Hashemi J, Tepper M, Vallin Spina T, . Computer vision tools for low-cost and noninvasive measurement of autism-related behaviors in infants. Autism Res Treat. 2014;2014:935686. doi: 10.1155/2014/935686. X-125045536
2416 Hawkins BL, Ryan JB, Cory AL, . Effects of Equine-Assisted Therapy on Gross Motor Skills of Two Children With AutismSpectrum Disorder. Therapeutic Recreation Journal. 2014 2014 2nd Quarter;48(2):135–49 15p. Language: English. Entry Date: 20140618. Revision Date: 20150820. Publication Type: Journal Article. X-1, X-3, X-4
2417 Head AM, McGillivray JA, Stokes MA. Gender differences in emotionality and sociability in children with autism spectrum disorders. Mol Autism. 2014;5(1):19. doi: 10.1186/2040-2392-5-19. X-124576331
2418 Hebert ML, Kehayia E, Prelock P, . Does occupational therapy play a role for communication in children with autism spectrum disorders? Int J Speech Lang Pathol. 2014 Dec;16(6):594–602. doi: 10.3109/17549507.2013.876665. X-124460071
2419 Hebron J, Humphrey N. Exposure to bullying among students with autism spectrum conditions: a multi-informant analysis of risk and protective factors. Autism. 2014 Aug;18(6):618–30. doi: 10.1177/1362361313495965. X-123886576
2420 Heitzer AM, Job MA, Pandit NK, . Should clinical trial research of psychotropic medication in autism control for gastrointestinal symptoms? J Clin Pharmacol. 2014 Oct;54(10):1093–6. doi: 10.1002/jcph.324. X-124788353
2421 Hemmat M, Rumple MJ, Mahon LW, . Short stature, digit anomalies and dysmorphic facial features are associated with the duplication of miR-17 ~ 92 cluster. Mol Cytogenet. 2014;7:27. doi: 10.1186/1755-8166-7-27. X-124739087
2422 Hepburn SL, Stern JA, Blakeley-Smith A, . Complex Psychiatric Comorbidity of Treatment-Seeking Youth With Autism Spectrum Disorder and Anxiety Symptoms. J Ment Health Res Intellect Disabil. 2014;7(4):359–78. doi: 10.1080/19315864.2014.932476. X-125960821
2423 Hesselmark E, Plenty S, Bejerot S. Group cognitive behavioural therapy and group recreational activity for adults with autism spectrum disorders: a preliminary randomized controlled trial. Autism. 2014 Aug;18(6):672–83. doi: 10.1177/1362361313493681. X-124089423
2424 Hill AP, Zuckerman KE, Hagen AD, . Aggressive Behavior Problems in Children with Autism Spectrum Disorders: Prevalence and Correlates in a Large Clinical Sample. Res Autism Spectr Disord. 2014 Sep 1;8(9):1121–33. doi: 10.1016/j.rasd.2014.05.006. X-125221619
2425 Hilton CL, Cumpata K, Klohr C, . Effects of exergaming on executive function and motor skills in children with autism spectrum disorder: a pilot study. Am J Occup Ther. 2014 Jan–Feb;68(1):57–65. doi: 10.5014/ajot.2014.008664. X-1, X-324367956
2426 Hirjak D, Wolf RC, Koch SC, . Neurological abnormalities in recent-onset schizophrenia and Asperger-syndrome. Frontiers in Psychiatry. 2014 2015-12-09;5 doi: 10.1016/j.jpsychires.2012.01.015; 2014-52575-001. X-124478733
2427 Hirota T, Veenstra-VanderWeele J, Hollander E, . Antiepileptic Medications in Autism Spectrum Disorder: A Systematic Review and Meta-Analysis. Journal of Autism & Developmental Disorders. 2014;44(4):948–57 10p. doi: 10.1007/s10803-013-1952-2. Language: English. Entry Date: 20140311. Revision Date: 20150710. Publication Type: Journal Article. X-224077782
2428 Hodgetts S, McConnell D, Zwaigenbaum L, . The impact of autism services on mothers’ occupational balance and participation. OTJR (Thorofare N J). 2014 Spring;34(2):81–92. doi: 10.3928/15394492-20130109-01. X-124651599
2429 Hoefman R, Payakachat N, van Exel J, . Caring for a child with autism spectrum disorder and parents’ quality of life: application of the CarerQol. J Autism Dev Disord. 2014 Aug;44(8):1933–45. doi: 10.1007/s10803-014-2066-1. X-124577786
2430 Hoffman K, Falcomata TS. An evaluation of resurgence of appropriate communication in individuals with autism who exhibit severe problem behavior. J Appl Behav Anal. 2014 Fall;47(3):651–6. doi: 10.1002/jaba.144. X-1, X-3, X-424910326
2431 Hogan-Brown AL, Hoedemaker RS, Gordon PC, . Eye-voice span during rapid automatized naming: evidence of reduced automaticity in individuals with autism spectrum disorder and their siblings. J Neurodev Disord. 2014;6(1):33. doi: 10.1186/1866-1955-6-33. X-125177372
2432 Holm MB, Baird JM, Kim YJ, . Therapeutic horseback riding outcomes of parent-identified goals for children with autism spectrum disorder: an ABA’ multiple case design examining dosing and generalization to the home and community. J Autism Dev Disord. 2014 Apr;44(4):937–47. doi: 10.1007/s10803-013-1949-x. X-3, X-424091469
2433 Hong YZ, Zhang XJ, Hong L, . [Influence of acupuncture of “Changqiang” (GV 1) on learning-memory ability and gap junction-related protein expression in the prefrontal cortex in autism rats]. Zhen Ci Yan Jiu. 2014 Jun;39(3):173–9. X-125069191
2434 Horder J, Wilson CE, Mendez MA, . Autistic traits and abnormal sensory experiences in adults. Journal of Autism and Developmental Disorders. 2014 2015-12-09;44(6):1461–9. doi: http://dx.doi.org/10.1007/s10803-013-2012-7; 2013-43128-001. X-124305777
2435 Horlin C, Falkmer M, Parsons R, . The cost of autism spectrum disorders. PLoS One. 2014;9(9):e106552. doi: 10.1371/journal.pone.0106552. X-125191755
2436 Horstmann M, Banek S, Gakis G, . Prospective evaluation of fluorescence-guided cystoscopy to detect bladder cancer in a high-risk population: results from the UroScreen-Study. Springerplus. 2014;3:24. doi: 10.1186/2193-1801-3-24. X-124478941
2437 Hovik KT, Egeland J, Isquith PK, . Distinct Patterns of Everyday Executive Function Problems Distinguish Children With Tourette Syndrome From Children With ADHD or Autism Spectrum Disorders. J Atten Disord. 2014 Sep 24 doi: 10.1177/1087054714550336. X-1
2438 Howard JS, Stanislaw H, Green G, . Comparison of behavior analytic and eclectic early interventions for young children with autism after three years. Res Dev Disabil. 2014 Dec;35(12):3326–44. doi: 10.1016/j.ridd.2014.08.021. X-125190094
2439 Hsia Y, Wong AY, Murphy DG, . Psychopharmacological prescriptions for people with autism spectrum disorder (ASD): a multinational study. Psychopharmacology (Berl). 2014 Mar;231(6):999–1009. doi: 10.1007/s00213-013-3263-x. X-124005531
2440 Huang CY, Yen HC, Tseng MH, . Impacts of autistic behaviors, emotional and behavioral problems on parenting stress in caregivers of children with autism. J Autism Dev Disord. 2014 Jun;44(6):1383–90. doi: 10.1007/s10803-013-2000-y. X-124287878
2441 Huke V, Turk J, Saeidi S, . The clinical implications of high levels of autism spectrum disorder features in anorexia nervosa: a pilot study. Eur Eat Disord Rev. 2014 Mar;22(2):116–21. doi: 10.1002/erv.2269. X-124277715
2442 Humm LB, Olsen D, Be M, . Simulated job interview improves skills for adults with serious mental illnesses. Stud Health Technol Inform. 2014;199:50–4. X-124875689
2443 Huss E, Sintzel F. [Outpatient and institutional care for the treatment of autism]. Soins Pediatr Pueric. 2014 Jan–Feb(276):20–3. X-1, X-2
2444 Hyvarinen L, Walthes R, Jacob N, . Current Understanding of What Infants See. Curr Ophthalmol Rep. 2014;2(4):142–9. doi: 10.1007/s40135-014-0056-2. X-125478306
2445 Irwin JR, Brancazio L. Seeing to hear? Patterns of gaze to speaking faces in children with autism spectrum disorders. Front Psychol. 2014;5:397. doi: 10.3389/fpsyg.2014.00397. X-124847297
2446 Ishihara Y, Sawada A, Nakamura M, . Development of a dose verification system for Vero4DRT using Monte Carlo method. J Appl Clin Med Phys. 2014;15(6):4961. doi: 10.1120/jacmp.v15i6.4961. X-125493521
2447 Isong IA, Rao SR, Holifield C, . Addressing dental fear in children with autism spectrum disorders: a randomized controlled pilot study using electronic screen media. Clin Pediatr (Phila). 2014 Mar;53(3):230–7. doi: 10.1177/0009922813517169. X-1, X-324391123
2448 Isshiki M, Tanaka S, Kuriu T, . Enhanced synapse remodelling as a common phenotype in mouse models of autism. Nat Commun. 2014;5:4742. doi: 10.1038/ncomms5742. X-125144834
2449 Iwanami A, Okajima Y, Ota H, . P300 component of event-related potentials in persons with asperger disorder. J Clin Neurophysiol. 2014 Oct;31(5):493–9. doi: 10.1097/wnp.0000000000000080. X-125271690
2450 Iwata K, Matsuzaki H, Tachibana T, . N-ethylmaleimide-sensitive factor interacts with the serotonin transporter and modulates its trafficking: implications for pathophysiology in autism. Mol Autism. 2014;5:33. doi: 10.1186/2040-2392-5-33. X-124834316
2451 Jahan A, Rezina-Parvin SZ, Bugum D. Familial, Social and Environmental Risk Factors in Autism: A Case-Control Study. Bangladesh Med Res Counc Bull. 2014 Dec;40(3):113–7. X-126402976
2452 Jain A, Spencer D, Yang W, . Injuries among children with autism spectrum disorder. Acad Pediatr. 2014 Jul–Aug;14(4):390–7. doi: 10.1016/j.acap.2014.03.012. X-124976351
2453 Jain T, Cautam V. Experience with Homoeopathic Remedies in the Treatment of ADHD and Autism. Homoeopathic Heritage. 2014;40(4):33–9 7p. Language: English. Entry Date: 20140915. Revision Date: 20150712. Publication Type: Journal Article. X-5
2454 Jalili M, Jahangiri N, Yazdi AA, . The effects of imitative vs. Cognitive methods on the speech development of children with autism. Iran J Child Neurol. 2014 Winter;8(1):37–46. X-124665326
2455 James LW, Pizur-Barnekow KA, Schefkind S. Online survey examining practitioners’ perceived preparedness in the early identification of autism. Am J Occup Ther. 2014 Jan–Feb;68(1):e13–20. doi: 10.5014/ajot.2014.009027. X-124367965
2456 Janeslatt G, Kottorp A, Granlund M. Evaluating intervention using time aids in children with disabilities. Scand J Occup Ther. 2014 May;21(3):181–90. doi: 10.3109/11038128.2013.870225. X-124417452
2457 Janssen FM, Landry G, Cambraia Lopes P, . Factors influencing the accuracy of beam range estimation in proton therapy using prompt gamma emission. Phys Med Biol. 2014 Aug 7;59(15):4427–41. doi: 10.1088/0031-9155/59/15/4427. X-125049223
2458 Jaschke AC. Music intervention as system: reversing hyper systemising in autism spectrum disorders to the comprehension of music as intervention. Med Hypotheses. 2014 Jan;82(1):40–8. doi: 10.1016/j.mehy.2013.11.001. X-124280561
2459 Jasien JM, Daimon CM, Wang R, . The effects of aging on the BTBR mouse model of autism spectrum disorder. Front Aging Neurosci. 2014;6:225. doi: 10.3389/fnagi.2014.00225. X-125225482
2460 Jeong JW, Tiwari VN, Behen ME, . In vivo detection of reduced Purkinje cell fibers with diffusion MRI tractography in children with autistic spectrum disorders. Front Hum Neurosci. 2014;8:110. doi: 10.3389/fnhum.2014.00110. X-124592234
2461 Jeste SS, Wu JY, Senturk D, . Early developmental trajectories associated with ASD in infants with tuberous sclerosis complex. Neurology. 2014;83(2):160–8 9p. doi: 10.1212/WNL.0000000000000568. Language: English. Entry Date: 20140912. Revision Date: 20150712. Publication Type: Journal Article. X-124920850
2462 Ji B, Sun M, Yi R, . Multidisciplinary parent education for caregivers of children with autism spectrum disorders. Arch Psychiatr Nurs. 2014 Oct;28(5):319–26. doi: 10.1016/j.apnu.2014.06.003. X-125439973
2463 Ji B, Zhao I, Turner C, . Predictors of health-related quality of life in Chinese caregivers of children with autism spectrum disorders: a cross-sectional study. Arch Psychiatr Nurs. 2014 Oct;28(5):327–32. doi: 10.1016/j.apnu.2014.06.001. X-125439974
2464 Jiménez L, Lorda M, Méndez C. Emulation and Mimicry in School Students with Typical Development and with High Functioning Autism. Journal of Autism & Developmental Disorders. 2014;44(7):1597–608 12p. doi: 10.1007/s10803-013-2027-0. Language: English. Entry Date: 20140620. Revision Date: 20150710. Publication Type: Journal Article. X-124362850
2465 Johnson N, Bree O, Lalley EE, . Effect of a social script iPad application for children with autism going to imaging. J Pediatr Nurs. 2014 Nov–Dec;29(6):651–9. doi: 10.1016/j.pedn.2014.04.007. X-124836052
2466 Johnson NL, Bekhet A, Robinson K, . Attributed meanings and strategies to prevent challenging behaviors of hospitalized children with autism: two perspectives. J Pediatr Health Care. 2014 Sep–Oct;28(5):386–93. doi: 10.1016/j.pedhc.2013.10.001. X-124239062
2467 Johnson RA, Danis M, Hafner-Eaton C. US state variation in autism insurance mandates: balancing access and fairness. Autism. 2014 Oct;18(7):803–14. doi: 10.1177/1362361314529191. X-124789870
2468 Jones I, McDonald L. Living with uncertainty: antidepressants and pregnancy. Br J Psychiatry. 2014 Aug;205(2):103–4. doi: 10.1192/bjp.bp.113.141713. X-125252318
2469 Jones J, Lerman DC, Lechago S. Assessing stimulus control and promoting generalization via video modeling when teaching social responses to children with autism. J Appl Behav Anal. 2014 Spring;47(1):37–50. doi: 10.1002/jaba.81. X-1, X-324114657
2470 Jones L, Hastings RP, Totsika V, . Child behavior problems and parental well-being in families of children with autism: the mediating role of mindfulness and acceptance. Am J Intellect Dev Disabil. 2014 Mar;119(2):171–85. doi: 10.1352/1944-7558-119.2.171. X-124679352
2471 Joosten AV, Safe AP. Management strategies of mothers of school-age children with autism: implications for practice. Aust Occup Ther J. 2014 Aug;61(4):249–58. doi: 10.1111/1440-1630.12116. X-124499184
2472 Joshi G, Faraone SV, Wozniak J, . Symptom Profile of ADHD in Youth With High-Functioning Autism Spectrum Disorder: A Comparative Study in Psychiatrically Referred Populations. J Atten Disord. 2014 Aug 1 doi: 10.1177/1087054714543368. X-1
2473 Jung M, Kosaka H, Saito DN, . Default mode network in young male adults with autism spectrum disorder: relationship with autism spectrum traits. Mol Autism. 2014;5:35. doi: 10.1186/2040-2392-5-35. X-124955232
2474 Kaale A, Fagerland MW, Martinsen EW, . Preschool-based social communication treatment for children with autism: 12-month follow-up of a randomized trial. J Am Acad Child Adolesc Psychiatry. 2014 Feb;53(2):188–98. doi: 10.1016/j.jaac.2013.09.019. X-124472253
2475 Kaboski JR, Diehl JJ, Beriont J, . Brief Report: A Pilot Summer Robotics Camp to Reduce Social Anxiety and Improve Social/Vocational Skills in Adolescents with ASD. J Autism Dev Disord. 2014 Jun 5 doi: 10.1007/s10803-014-2153-3. X-1, X-4
2476 Kanne SM, Mazurek MO, Sikora D, . The Autism Impact Measure (AIM): initial development of a new tool for treatment outcome measurement. J Autism Dev Disord. 2014 Jan;44(1):168–79. doi: 10.1007/s10803-013-1862-3. X-123748386
2477 Kara B, Mukaddes NM, Altinkaya I, . Using the modified checklist for autism in toddlers in a well-child clinic in Turkey: adapting the screening method based on culture and setting. Autism. 2014 Apr;18(3):331–8. doi: 10.1177/1362361312467864. X-123175752
2478 Karvat G, Kimchi T. Acetylcholine elevation relieves cognitive rigidity and social deficiency in a mouse model of autism. Neuropsychopharmacology. 2014 Mar;39(4):831–40. doi: 10.1038/npp.2013.274. X-124096295
2479 Kasari C, Kaiser A, Goods K, . Communication interventions for minimally verbal children with autism: a sequential multiple assignment randomized trial. J Am Acad Child Adolesc Psychiatry. 2014 Jun;53(6):635–46. doi: 10.1016/j.jaac.2014.01.019. X-124839882
2480 Kasari C, Lawton K, Shih W, . Caregiver-mediated intervention for low-resourced preschoolers with autism: an RCT. Pediatrics. 2014 Jul;134(1):e72–9. doi: 10.1542/peds.2013-3229. X-124958585
2481 Kasari C, Siller M, Huynh LN, . Randomized controlled trial of parental responsiveness intervention for toddlers at high risk for autism. Infant Behav Dev. 2014 Nov;37(4):711–21. doi: 10.1016/j.infbeh.2014.08.007. X-125260191
2482 Kasarpalkar NJ, Kothari ST, Dave UP. Brain-Derived Neurotrophic Factor in children with Autism Spectrum Disorder. Ann Neurosci. 2014 Oct;21(4):129–33. doi: 10.5214/ans.0972.7531.210403. X-125452672
2483 Kasirer A, Mashal N. Verbal creativity in autism: comprehension and generation of metaphoric language in high-functioning autism spectrum disorder and typical development. Front Hum Neurosci. 2014;8:615. doi: 10.3389/fnhum.2014.00615. X-125157225
2484 Kato F, Iwanaga R, Chono M, . Relationship between Sympathetic Skin Responses and Auditory Hypersensitivity to Different Auditory Stimuli. J Phys Ther Sci. 2014 Jul;26(7):1087–91. doi: 10.1589/jpts.26.1087. X-125140103
2485 Kaye L, Kurtz M, Tierney C, . Gaze maintenance and autism spectrum disorder. J Dev Behav Pediatr. 2014 Nov–Dec;35(9):610–2. doi: 10.1097/dbp.0000000000000106. X-125325757
2486 Kenworthy L, Anthony LG, Naiman DQ, . Randomized controlled effectiveness trial of executive function intervention for children on the autism spectrum. J Child Psychol Psychiatry. 2014 Apr;55(4):374–83. doi: 10.1111/jcpp.12161. X-124256459
2487 Kerekes N, Lundstrom S, Chang Z, . Oppositional defiant- and conduct disorder-like problems: neurodevelopmental predictors and genetic background in boys and girls, in a nationwide twin study. PeerJ. 2014;2:e359. doi: 10.7717/peerj.359. X-124795851
2488 Key AP, Ibanez LV, Henderson HA, . Positive Affect Processing and Joint Attention in Infants at High Risk for Autism: An Exploratory Study. J Autism Dev Disord. 2014 Jul 24 doi: 10.1007/s10803-014-2191-x. X-1
2489 Kim JW, Seung H, Kwon KJ, . Subchronic treatment of donepezil rescues impaired social, hyperactive, and stereotypic behavior in valproic acid-induced animal model of autism. PLoS One. 2014;9(8):e104927. doi: 10.1371/journal.pone.0104927. X-125133713
2490 Kimhi Y. Theory of Mind Abilities and Deficits in Autism Spectrum Disorders. Topics in Language Disorders. 2014;34(4):329–43 15p. doi: 10.1097/TLD.0000000000000033. Language: English. Entry Date: 20141124. Revision Date: 20150712. Publication Type: Journal Article. X-1
2491 Kimple KS, Bartelt EA, Wysocki KL, . Performance of the Modified Checklist for Autism in Toddlers in Spanish-speaking patients. Clin Pediatr (Phila). 2014 Jun;53(7):632–8. doi: 10.1177/0009922814522346. X-124550559
2492 Klusek J, Martin GE, Losh M. A comparison of pragmatic language in boys with autism and fragile X syndrome. J Speech Lang Hear Res. 2014 Oct;57(5):1692–707. doi: 10.1044/2014_jslhr-l-13-0064. X-124686468
2493 Knopf A. Kids TLC helps families and children, focusing on trauma and partnerships. Behav Healthc. 2014 May–Jun;34(3):55–6. X-125065158
2494 Kobari-Wright VV, Miguel CF. The effects of listener training on the emergence of categorization and speaker behavior in children with autism. J Appl Behav Anal. 2014 Summer;47(2):431–6. doi: 10.1002/jaba.115. X-3, X-424740431
2495 Koegel L, Singh A, Koegel R, . Assessing and Improving Early Social Engagement in Infants. J Posit Behav Interv. 2014 Apr;16(2):69–80. doi: 10.1177/1098300713482977. X-125313271
2496 Koegel RL, Bradshaw JL, Ashbaugh K, . Improving question-asking initiations in young children with autism using pivotal response treatment. J Autism Dev Disord. 2014 Apr;44(4):816–27. doi: 10.1007/s10803-013-1932-6. X-3, X-424014174
2497 Koehler AD, Fagnano M, Montes G, . Elevated burden for caregivers of children with persistent asthma and a developmental disability. Matern Child Health J. 2014 Nov;18(9):2080–8. doi: 10.1007/s10995-014-1455-6. X-124619226
2498 Koelkebeck K, Riedel A, Ohrmann P, . [High-functioning autism spectrum disorders in adulthood]. Nervenarzt. 2014 Jul;85(7):891–900; quiz 1–2. doi: 10.1007/s00115-014-4050-6. X-124969950
2499 Koenig KP, Feldman JM, Siegel D, . Issues in implementing a comprehensive intervention for public school children with autism spectrum disorders. J Prev Interv Community. 2014;42(4):248–63. doi: 10.1080/10852352.2014.943638. X-125321640
2500 Kohl S, Wolters C, Gruendler TO, . Prepulse inhibition of the acoustic startle reflex in high functioning autism. PLoS One. 2014;9(3):e92372. doi: 10.1371/journal.pone.0092372. X-124643088
2501 Kolevzon A, Bush L, Wang AT, . A pilot controlled trial of insulin-like growth factor-1 in children with Phelan-McDermid syndrome. Mol Autism. 2014;5(1):54. doi: 10.1186/2040-2392-5-54. X-1, X-425685306
2502 Kontorinis G, Lloyd SK, Henderson L, . Cochlear implantation in children with auditory neuropathy spectrum disorders. Cochlear Implants Int. 2014 May;15(Suppl 1):S51–4. doi: 10.1179/1467010014z.000000000157. X-124869444
2503 Koolen S, Vissers C, Egger J, . How Stimulus and Task Complexity Affect Monitoring in High-Functioning Adults with Autism Spectrum Disorder. Journal of Autism & Developmental Disorders. 2014;44(10):2499–513 15p. doi: 10.1007/s10803-014-2119-5. Language: English. Entry Date: 20140922. Revision Date: 20151001. Publication Type: Journal Article. X-124838251
2504 Koren EV, Kupriyanova TA, Dubinskaya AO, . [An influence of mental disorder in the child on the parents in the context of differentiated approaches to psychosocial interventions on childhood psychiatry]. Zh Nevrol Psikhiatr Im S S Korsakova. 2014;114(10):14–9. X-1
2505 Korotchenko S, Cingolani LA, Kuznetsova T, . Modulation of network activity and induction of homeostatic synaptic plasticity by enzymatic removal of heparan sulfates. Philos Trans R Soc Lond B Biol Sci. 2014 Oct 19;369(1654):20140134. doi: 10.1098/rstb.2014.0134. X-125225107
2506 Koterba EA, Leezenbaum NB, Iverson JM. Object exploration at 6 and 9 months in infants with and without risk for autism. Autism: The International Journal of Research & Practice. 2014;18(2):97–105 9p. doi: 10.1177/1362361312464826. Language: English. Entry Date: 20140128. Revision Date: 20150710. Publication Type: Journal Article. X-123175749
2507 Kover ST, Davidson MM, Sindberg HA, . Use of the ADOS for assessing spontaneous expressive language in young children with ASD: a comparison of sampling contexts. J Speech Lang Hear Res. 2014 Dec;57(6):2221–33. doi: 10.1044/2014_jslhr-l-13-0330. X-125093577
2508 Kozhushko N, Kropotov Iu D, Matveev Iu K, . [Brain structures and functional pecularities in children with mental disorders and transcranial direct current stimulation]. Fiziol Cheloveka. 2014 Jul–Aug;40(4):36–43. X-1
2509 Kramer J, Rubin A, Coster W, . Strategies to address participant misrepresentation for eligibility in Web-based research. Int J Methods Psychiatr Res. 2014 Mar;23(1):120–9. doi: 10.1002/mpr.1415. X-124431134
2510 Krawczyk DC, Kandalaft MR, Didehbani N, . An investigation of reasoning by analogy in schizophrenia and autism spectrum disorder. Front Hum Neurosci. 2014;8:517. doi: 10.3389/fnhum.2014.00517. X-125191240
2511 Kronenberg LM, Slager-Visscher K, Goossens PJ, . Everyday life consequences of substance use in adult patients with a substance use disorder (SUD) and co-occurring attention deficit/hyperactivity disorder (ADHD) or autism spectrum disorder (ASD): a patient’s perspective. BMC Psychiatry. 2014;14:264. doi: 10.1186/s12888-014-0264-1. X-125234344
2512 Kuhn M, Bransfield R. Divergent opinions of proper Lyme disease diagnosis and implications for children co-morbid with autism spectrum disorder. Med Hypotheses. 2014 Sep;83(3):321–5. doi: 10.1016/j.mehy.2014.06.005. X-124986703
2513 Kumar M, Duda JT, Hwang WT, . High resolution magnetic resonance imaging for characterization of the neuroligin-3 knock-in mouse model associated with autism spectrum disorder. PLoS One. 2014;9(10):e109872. doi: 10.1371/journal.pone.0109872. X-125299583
2514 Kumazaki H, Watanabe K, Imasaka Y, . Risperidone-associated urinary incontinence in patients with autistic disorder with mental retardation. J Clin Psychopharmacol. 2014 Oct;34(5):624–6. doi: 10.1097/jcp.0000000000000197. X-1, X-325118082
2515 Kushki A, Brian J, Dupuis A, . Functional autonomic nervous system profile in children with autism spectrum disorder. Mol Autism. 2014;5:39. doi: 10.1186/2040-2392-5-39. X-125031832
2516 Kwok SY, Leung CL, Wong DF. Marital satisfaction of Chinese mothers of children with autism and intellectual disabilities in Hong Kong. J Intellect Disabil Res. 2014 Dec;58(12):1156–71. doi: 10.1111/jir.12116. X-124450394
2517 LaGasse AB. Effects of a music therapy group intervention on enhancing social skills in children with autism. J Music Ther. 2014 Fall;51(3):250–75. doi: 10.1093/jmt/thu012. X-425053766
2518 Lagunju IA, Bella-Awusah TT, Omigbodun OO. Autistic disorder in Nigeria: profile and challenges to management. Epilepsy Behav. 2014 Oct;39:126–9. doi: 10.1016/j.yebeh.2014.08.020. X-125240124
2519 Lajiness-O’Neill R, Richard AE, Moran JE, . Neural synchrony examined with magnetoencephalography (MEG) during eye gaze processing in autism spectrum disorders: preliminary findings. J Neurodev Disord. 2014;6(1):15. doi: 10.1186/1866-1955-6-15. X-124976870
2520 Lake JK, Weiss JA, Dergal J, . Child, parent, and service predictors of psychotropic polypharmacy among adolescents and young adults with an autism spectrum disorder. J Child Adolesc Psychopharmacol. 2014 Nov;24(9):486–93. doi: 10.1089/cap.2014.0011. X-125329798
2521 Lanning BA, Baier ME, Ivey-Hatz J, . Effects of equine assisted activities on autism spectrum disorder. J Autism Dev Disord. 2014 Aug;44(8):1897–907. doi: 10.1007/s10803-014-2062-5. X-424526337
2522 LaRusso L. Competencies for Providing Evidence-Based Care. Nursing for Women’s Health. 2014;18(2):105–10 6p. doi: 10.1111/1751-486X.12106. Language: English. Entry Date: 20140422. Revision Date: 20150710. Publication Type: Journal Article. X-1
2523 Laub WU, Crilly R. Clinical radiation therapy measurements with a new commercial synthetic single crystal diamond detector. J Appl Clin Med Phys. 2014;15(6):4890. doi: 10.1120/jacmp.v15i6.4890. X-125493512
2524 Lavelle TA, Weinstein MC, Newhouse JP, . Economic burden of childhood autism spectrum disorders. Pediatrics. 2014 Mar;133(3):e520–9. doi: 10.1542/peds.2013-0763. X-124515505
2525 Lazar M, Miles LM, Babb JS, . Axonal deficits in young adults with High Functioning Autism and their impact on processing speed. Neuroimage Clin. 2014;4:417–25. doi: 10.1016/j.nicl.2014.01.014. X-124624327
2526 Lee K, Yoon K, Park KS, . Treatment of extensive comminuted mandibular fracture between both mandibular angles with bilateral condylar fractures using a reconstruction plate: a case report. J Korean Assoc Oral Maxillofac Surg. 2014 Jun;40(3):135–9. doi: 10.5125/jkaoms.2014.40.3.135. X-125045641
2527 Leezenbaum NB, Campbell SB, Butler D, . Maternal verbal responses to communication of infants at low and heightened risk of autism. Autism. 2014 Aug;18(6):694–703. doi: 10.1177/1362361313491327. X-124113343
2528 Legradi J, El Abdellaoui N, van Pomeren M, . Comparability of behavioural assays using zebrafish larvae to assess neurotoxicity. Environ Sci Pollut Res Int. 2014 Nov 18 doi: 10.1007/s11356-014-3805-8. X-1
2529 Leonard HC, Bedford R, Charman T, . Motor development in children at risk of autism: A follow-up study of infant siblings. Autism: The International Journal of Research & Practice. 2014;18(3):281–91 11p. doi: 10.1177/1362361312470037. Language: English. Entry Date: 20140321. Revision Date: 20150710. Publication Type: Journal Article. X-124101718
2530 Lepage JF, Lortie M, Deal CL, . Empathy, autistic traits, and motor resonance in adults with Turner syndrome. Soc Neurosci. 2014;9(6):601–9. doi: 10.1080/17470919.2014.944317. X-125079009
2531 Lerna A, Esposito D, Conson M, . Long-term effects of PECS on social-communicative skills of children with autism spectrum disorders: a follow-up study. Int J Lang Commun Disord. 2014 Jul–Aug;49(4):478–85. doi: 10.1111/1460-6984.12079. X-124655345
2532 Lester JN, Karim K, O’Reilly M. Autism itself actually isn’t a disability’: Negotiating a ‘normal’ versus ‘abnormal’ autistic identity. Commun Med. 2014;11(2):139–52. X-126596122
2533 Levey EJ. Effective Treatment Strategies for Autism During the First Five Years of Development. J Am Psychoanal Assoc. 2014 Jun 9;62(3):475–84. doi: 10.1177/0003065114539839. X-1, X-2, X-324913552
2534 Levin DS, Volkert VM, Piazza CC. A multi-component treatment to reduce packing in children with feeding and autism spectrum disorders. Behav Modif. 2014 Nov;38(6):940–63. doi: 10.1177/0145445514550683. X-3, X-425271069
2535 Li LY, Jiang N, Zhao Y. Could acupuncture have a role in the treatment of autism spectrum disorder via modulation of BDNF expression and activation? Acupunct Med. 2014 Dec;32(6):503–5. doi: 10.1136/acupmed-2014-010602. X-1, X-2, X-325257393
2536 Li SO, Wang JL, Bjorklund G, . Serum copper and zinc levels in individuals with autism spectrum disorders. Neuroreport. 2014 Oct 22;25(15):1216–20. doi: 10.1097/wnr.0000000000000251. X-125162784
2537 Li YW, Ma L, Sui B, . Etomidate with or without flumazenil anesthesia for stem cell transplantation in autistic children. Drug Metabol Drug Interact. 2014;29(1):47–51. doi: 10.1515/dmdi-2013-0043. X-124225126
2538 Li Z, Tang J, Li H, . Shorter telomere length in peripheral blood leukocytes is associated with childhood autism. Sci Rep. 2014;4:7073. doi: 10.1038/srep07073. X-125399515
2539 Liao ST, Hwang YS, Chen YJ, . Home-based DIR/Floortime intervention program for preschool children with autism spectrum disorders: preliminary findings. Phys Occup Ther Pediatr. 2014 Nov;34(4):356–67. doi: 10.3109/01942638.2014.918074. X-3, X-424865120
2540 Libero LE, Maximo JO, Deshpande HD, . The role of mirroring and mentalizing networks in mediating action intentions in autism. Mol Autism. 2014;5(1):50. doi: 10.1186/2040-2392-5-50. X-125352976
2541 Libertus K, Landa RJ. Scaffolded reaching experiences encourage grasping activity in infants at high risk for autism. Front Psychol. 2014;5:1071. doi: 10.3389/fpsyg.2014.01071. X-125295021
2542 Libertus K, Sheperd KA, Ross SW, . Limited fine motor and grasping skills in 6-month-old infants at high risk for autism. Child Development. 2014;85(6):2218–31 14p. doi: 10.1111/cdev.12262. Language: English. Entry Date: 20150821. Revision Date: 20151104. Publication Type: journal article. X-124978128
2543 Lieberman-Betz RG, Yoder P, Stone WL, . An illustration of using multiple imputation versus listwise deletion analyses: the effect of Hanen’s “More than words” on parenting stress. Am J Intellect Dev Disabil. 2014 Sep;119(5):472–86. doi: 10.1352/1944-7558-119.5.472. X-125148059
2544 Li-Grining CP, Durlak JA. The design and implementation of early childhood intervention programs: informing efforts to address risk and promote resilience. J Prev Interv Community. 2014;42(4):243–7. doi: 10.1080/10852352.2014.943640. X-125321639
2545 Lin IF, Kashino M, Ohta H, . The effect of intranasal oxytocin versus placebo treatment on the autonomic responses to human sounds in autism: a single-blind, randomized, placebo-controlled, crossover design study. Mol Autism. 2014;5(1):20. doi: 10.1186/2040-2392-5-20. X-124576333
2546 Lin SC, Margolis B, Yu SM, . The role of medical home in emergency department use for children with developmental disabilities in the United States. Pediatr Emerg Care. 2014 Aug;30(8):534–9. doi: 10.1097/pec.0000000000000184. X-125062298
2547 Lind SE, Bowler DM, Raber J. Spatial navigation, episodic memory, episodic future thinking, and theory of mind in children with autism spectrum disorder: evidence for impairments in mental simulation? Front Psychol. 2014;5:1411. doi: 10.3389/fpsyg.2014.01411. X-125538661
2548 Lionello-Denolf KM, Farber R, Jones BM, . Thematic Matching as Remedial Teaching for Symbolic Matching for Individuals with Autism Spectrum Disorder. Res Autism Spectr Disord. 2014 May 1;8(5):455–62. doi: 10.1016/j.rasd.2014.01.004. X-1, X-3, X-424634695
2549 Little LM, Sideris J, Ausderau K, . Activity participation among children with autism spectrum disorder. Am J Occup Ther. 2014 Mar–Apr;68(2):177–85. doi: 10.5014/ajot.2014.009894. X-124581404
2550 Liu L, Lei J, Sanders SJ, . DAWN: a framework to identify autism genes and subnetworks using gene expression and genetics. Mol Autism. 2014;5(1):22. doi: 10.1186/2040-2392-5-22. X-124602502
2551 Locke J, Rotheram-Fuller E, Xie M, . Correlation of cognitive and social outcomes among children with autism spectrum disorder in a randomized trial of behavioral intervention. Autism. 2014 May;18(4):370–5. doi: 10.1177/1362361313479181. X-1, X-324104511
2552 Lofkvist U, Almkvist O, Lyxell B, . Lexical and semantic ability in groups of children with cochlear implants, language impairment and autism spectrum disorder. Int J Pediatr Otorhinolaryngol. 2014 Feb;78(2):253–63. doi: 10.1016/j.ijporl.2013.11.017. X-124332667
2553 Logan SL, Carpenter L, Leslie RS, . Rates and predictors of adherence to psychotropic medications in children with autism spectrum disorders. J Autism Dev Disord. 2014 Nov;44(11):2931–48. doi: 10.1007/s10803-014-2156-0. X-124929833
2554 Lopez-Pison J, Garcia-Jimenez MC, Monge-Galindo L, . Our experience with the aetiological diagnosis of global developmental delay and intellectual disability: 2006–2010. Neurologia. 2014 Sep;29(7):402–7. doi: 10.1016/j.nrl.2013.10.006. X-124332781
2555 Lotan A, Fenckova M, Bralten J, . Neuroinformatic analyses of common and distinct genetic components associated with major neuropsychiatric disorders. Front Neurosci. 2014;8:331. doi: 10.3389/fnins.2014.00331. X-125414627
2556 Loth E, Spooren W, Murphy DG. New treatment targets for autism spectrum disorders: EU-AIMS. Lancet Psychiatry. 2014 Nov;1(6):413–5. doi: 10.1016/s2215-0366(14)00004-2. X-126361185
2557 Loukusa S, Makinen L, Kuusikko-Gauffin S, . Theory of mind and emotion recognition skills in children with specific language impairment, autism spectrum disorder and typical development: group differences and connection to knowledge of grammatical morphology, word-finding abilities and verbal working memory. Int J Lang Commun Disord. 2014 Jul–Aug;49(4):498–507. doi: 10.1111/1460-6984.12091. X-124888967
2558 Lowth M. Detecting developmental delay. Practice Nurse. 2014;44(5):24–8 5p. Language: English. Entry Date: 20140602. Revision Date: 20150712. Publication Type: Journal Article. X-1
2559 Lozano R, Hagerman RJ, Duyzend M, . Genomic studies in fragile X premutation carriers. J Neurodev Disord. 2014;6(1):27. doi: 10.1186/1866-1955-6-27. X-125170347
2560 Lucas R, Norbury CF. Orthography facilitates vocabulary learning for children with autism spectrum disorders (ASD). Q J Exp Psychol (Hove). 2014;67(7):1317–34. doi: 10.1080/17470218.2013.859714. X-1, X-324313313
2561 Ludlow A, Mohr B, Whitmore A, . Auditory processing and sensory behaviours in children with autism spectrum disorders as revealed by mismatch negativity. Brain Cogn. 2014 Apr;86:55–63. doi: 10.1016/j.bandc.2014.01.016. X-124565813
2562 Lugo JN, Smith GD, Arbuckle EP, . Deletion of PTEN produces autism-like behavioral deficits and alterations in synaptic proteins. Front Mol Neurosci. 2014;7:27. doi: 10.3389/fnmol.2014.00027. X-124795561
2563 Lumeng JC. Commentary on ‘successful use of intravenous dexmedetomidine for magnetic resonance imaging sedation in autistic children’. Southern Medical Journal. 2014;107(9):565–6 2p. doi: 10.14423/SMJ.0000000000000161. Language: English. Entry Date: 20141114. Revision Date: 20150712. Publication Type: Journal Article. X-125188620
2564 Ma M-Y, Lee Y-H. Children with autism and composite tactile-visual toys during parent-child interaction. Interaction Studies: Social Behaviour and Communication in Biological and Artificial Systems. 2014 2015-02-24;15(2):260–91. doi: http://dx.doi.org/10.1075/is.15.2.13ma; 2014-41524-013. X-1
2565 MacDonald M, Lord C, Ulrich DA. Motor skills and calibrated autism severity in young children with autism spectrum disorder. Adapt Phys Activ Q. 2014 Apr;31(2):95–105. doi: 10.1123/apaq.2013-0068. X-124762385
2566 MacDonald R, Parry-Cruwys D, Dupere S, . Assessing progress and outcome of early intensive behavioral intervention for toddlers with autism. Res Dev Disabil. 2014 Dec;35(12):3632–44. doi: 10.1016/j.ridd.2014.08.036. X-325241118
2567 Macpherson K, Charlop MH, Miltenberger CA. Using Portable Video Modeling Technology to Increase the Compliment Behaviors of Children with Autism During Athletic Group Play. J Autism Dev Disord. 2014 Feb 27 doi: 10.1007/s10803-014-2072-3. X-3, X-4
2568 Madsen GF, Bilenberg N, Cantio C, . Increased prepulse inhibition and sensitization of the startle reflex in autistic children. Autism Res. 2014 Feb;7(1):94–103. doi: 10.1002/aur.1337. X-124124111
2569 Majdalany LM, Wilder DA, Greif A, . Comparing massed-trial instruction, distributed-trial instruction, and task interspersal to teach tacts to children with autism spectrum disorders. J Appl Behav Anal. 2014 Fall;47(3):657–62. doi: 10.1002/jaba.149. X-3, X-424988891
2570 Malandraki GA, Roth M, Sheppard JJ. Telepractice for pediatric Dysphagia: a case study. Int J Telerehabil. 2014 Spring;6(1):3–16. doi: 10.5195/ijt.2014.6135. X-1
2571 Maloney A, Mick EO, Frazier J. Aripiprazole decreases irritability in 12 out of 14 youth with autism spectrum disorders. J Child Adolesc Psychopharmacol. 2014 Aug;24(6):357–9. doi: 10.1089/cap.2013.0143. X-3, X-424828130
2572 Malow BA, Adkins KW, Reynolds A, . Parent-based sleep education for children with autism spectrum disorders. J Autism Dev Disord. 2014 Jan;44(1):216–28. doi: 10.1007/s10803-013-1866-z. X-123754339
2573 Mandelberg J, Frankel F, Cunningham T, . Long-term outcomes of parent-assisted social skills intervention for high-functioning children with autism spectrum disorders. Autism. 2014 Apr;18(3):255–63. doi: 10.1177/1362361312472403. X-1, X-323996903
2574 Mangerud WL, Bjerkeset O, Lydersen S, . Physical activity in adolescents with psychiatric disorders and in the general population. Child Adolesc Psychiatry Ment Health. 2014;8(1):2. doi: 10.1186/1753-2000-8-2. X-124450542
2575 Manouilenko I, Eriksson JM, Humble MB, . Minor physical anomalies in adults with autism spectrum disorder and healthy controls. Autism Res Treat. 2014;2014:743482. doi: 10.1155/2014/743482. X-124782925
2576 Markwick L, Smith C, Mick D. Functional behavioral analysis and social scripting for the older patient with schizophrenia: a staff development program. Issues Ment Health Nurs. 2014 Nov;35(11):883–90. doi: 10.3109/01612840.2014.897777. X-125353301
2577 Marroquin M, Alvero A, Sturmey P. Evaluation of the observer effect on compliance training in adolescents with autism. Res Dev Disabil. 2014 Feb;35(2):537–40. doi: 10.1016/j.ridd.2013.11.008. X-124378631
2578 Marrus N, Underwood-Riordan H, Randall F, . Lack of effect of risperidone on core autistic symptoms: data from a longitudinal study. J Child Adolesc Psychopharmacol. 2014 Nov;24(9):513–8. doi: 10.1089/cap.2014.0055. X-325361070
2579 Marrus N, Veenstra-Vanderweele J, Hellings JA, . Training of child and adolescent psychiatry fellows in autism and intellectual disability. Autism. 2014 May;18(4):471–5. doi: 10.1177/1362361313477247. X-124113341
2580 Marshall ES. Increasing prevalence of autism: implications for school nursing. NASN Sch Nurse. 2014 Sep;29(5):241–3. X-125272410
2581 Martin HG, Manzoni OJ. Late onset deficits in synaptic plasticity in the valproic acid rat model of autism. Front Cell Neurosci. 2014;8:23. doi: 10.3389/fncel.2014.00023. X-124550781
2582 Martínez-Sanchis S. Neurobiological foundations of multisensory integration in people with autism spectrum disorders: The role of the medial prefrontal cortex. Frontiers in Human Neuroscience. 2014 2015-12-09;8; 2015-25642-001. X-124478674
2583 Maskey M, Lowry J, Rodgers J, . Reducing specific phobia/fear in young people with autism spectrum disorders (ASDs) through a virtual reality environment intervention. PLoS One. 2014;9(7):e100374. doi: 10.1371/journal.pone.0100374. X-3, X-424987957
2584 Mason R, Kamps D, Turcotte A, . Peer Mediation to Increase Communication and Interaction at Recess for Students with Autism Spectrum Disorders. Res Autism Spectr Disord. 2014 Mar;8(3):334–44. doi: 10.1016/j.rasd.2013.12.014. X-1, X-326180543
2585 Masterson TL, Dimitriou F, Turko K, . Developing undergraduate coursework in autism spectrum disorders. J Autism Dev Disord. 2014 Oct;44(10):2646–9. doi: 10.1007/s10803-012-1673-y. X-123054203
2586 Matsuzaki J, Kagitani-Shimono K, Sugata H, . Progressively increased M50 responses to repeated sounds in autism spectrum disorder with auditory hypersensitivity: a magnetoencephalographic study. PLoS One. 2014;9(7):e102599. doi: 10.1371/journal.pone.0102599. X-1, X-325054201
2587 Mavranezouli I, Megnin-Viggars O, Cheema N, . The cost-effectiveness of supported employment for adults with autism in the United Kingdom. Autism. 2014 Nov;18(8):975–84. doi: 10.1177/1362361313505720. X-124126866
2588 Maxwell BG, Lobato RL, Cason MB, . Perioperative morbidity and mortality of cardiothoracic surgery in patients with a do-not-resuscitate order. PeerJ. 2014;2:e245. doi: 10.7717/peerj.245. X-124498575
2589 Mayer JL, Heaton PF. Age and sensory processing abnormalities predict declines in encoding and recall of temporally manipulated speech in high-functioning adults with ASD. Autism Res. 2014 Feb;7(1):40–9. doi: 10.1002/aur.1333. X-124106132
2590 Mazefsky CA, Schreiber DR, Olino TM, . The association between emotional and behavioral problems and gastrointestinal symptoms among children with high-functioning autism. Autism. 2014 Jul;18(5):493–501. doi: 10.1177/1362361313485164. X-124104507
2591 Mazurek MO, Handen BL, Wodka EL, . Age at first autism spectrum disorder diagnosis: the role of birth cohort, demographic factors, and clinical features. J Dev Behav Pediatr. 2014 Nov–Dec;35(9):561–9. doi: 10.1097/dbp.0000000000000097. X-125211371
2592 Mazza M, Pino MC, Mariano M, . Affective and cognitive empathy in adolescents with autism spectrum disorder. Front Hum Neurosci. 2014;8:791. doi: 10.3389/fnhum.2014.00791. X-125339889
2593 McConachie H, McLaughlin E, Grahame V, . Group therapy for anxiety in children with autism spectrum disorder. Autism. 2014 Aug;18(6):723–32. doi: 10.1177/1362361313488839. X-124101715
2594 McCormick C, Hessl D, Macari SL, . Electrodermal and behavioral responses of children with autism spectrum disorders to sensory and repetitive stimuli. Autism Research. 2014 2015-12-09;7(4):468–80. doi: http://dx.doi.org/10.1002/aur.1382; 2014-18958-001. X-124788961
2595 McCracken JT, Badashova KK, Posey DJ, . Positive effects of methylphenidate on hyperactivity are moderated by monoaminergic gene variants in children with autism spectrum disorders. Pharmacogenomics J. 2014 Jun;14(3):295–302. doi: 10.1038/tpj.2013.23.23856854
2596 McFadden B, Kamps D, Heitzman-Powell L. Social Communication Effects of Peer-Mediated Recess Intervention for Children with Autism. Res Autism Spectr Disord. 2014 Dec;8(12):1699–712. doi: 10.1016/j.rasd.2014.08.015. X-3, X-426312064
2597 McGillivray JA, Evert HT. Group cognitive behavioural therapy program shows potential in reducing symptoms of depression and stress among young people with ASD. J Autism Dev Disord. 2014 Aug;44(8):2041–51. doi: 10.1007/s10803-014-2087-9. X-124634065
2598 McGonigle JJ, Migyanka JM, Glor-Scheib SJ, . Development and evaluation of educational materials for pre-hospital and emergency department personnel on the care of patients with autism spectrum disorder. J Autism Dev Disord. 2014 May;44(5):1252–9. doi: 10.1007/s10803-013-1962-0. X-124091472
2599 McLean RL, Johnson Harrison A, Zimak E, . Executive function in probands with autism with average IQ and their unaffected first-degree relatives. J Am Acad Child Adolesc Psychiatry. 2014 Sep;53(9):1001–9. doi: 10.1016/j.jaac.2014.05.019. X-125151423
2600 McMahon J, Cullinan V. Education programmes for young children with Autism Spectrum Disorder: an Evaluation Framework. Res Dev Disabil. 2014 Dec;35(12):3689–97. doi: 10.1016/j.ridd.2014.09.004. X-125262014
2601 Meilleur AA, Berthiaume C, Bertone A, . Autism-specific covariation in perceptual performances: “g” or “p” factor? PLoS One. 2014;9(8):e103781. doi: 10.1371/journal.pone.0103781. X-125117450
2602 Meyenburg B. [Gender dysphoria in adolescents: difficulties in treatment]. Prax Kinderpsychol Kinderpsychiatr. 2014;63(6):510–22. X-125296511
2603 Meyer MA. [Consultations with a nurse specialized in cognitive behavioural therapies]. Soins Psychiatr. 2014 Nov–Dec(295):42–4. X-1, X-325562920
2604 Miller M, Chukoskie L, Zinni M, . Dyspraxia, motor function and visual–motor integration in autism. Behavioural Brain Research. 2014 2015-07-22;269:95–102. doi: 10.2522/ptj.20100294 http://dx.doi.org/10.1016/j.bbr.2014.04.011; 2014-23423-015. X-124742861
2605 Milner LC, Cho MK. Focusing on Cause or Cure?: Priorities and Stakeholder Presence in Childhood Psychiatry Research. AJOB Prim Res. 2014 Jan 1;5(1):44–55. doi: 10.1080/21507716.2013.811315. X-124729931
2606 Miltenberger CA, Charlop MH. Increasing the athletic group play of children with autism. J Autism Dev Disord. 2014 Jan;44(1):41–54. doi: 10.1007/s10803-013-1850-7. X-3, X-423700189
2607 Mire SS, Nowell KP, Kubiszyn T, . Psychotropic medication use among children with autism spectrum disorders within the Simons Simplex Collection: are core features of autism spectrum disorder related? Autism. 2014 Nov;18(8):933–42. doi: 10.1177/1362361313498518. X-1, X-324031086
2608 Misquiatti AR, Brito MC, Olivati AG, . Sociocognitive performance in autism spectrum disorders and interference of the therapeutic environment. Codas. 2014 Sep–Oct;26(5):402–6. X-3, X-425388074
2609 Missault S, Van den Eynde K, Vanden Berghe W, . The risk for behavioural deficits is determined by the maternal immune response to prenatal immune challenge in a neurodevelopmental model. Brain Behav Immun. 2014 Nov;42:138–46. doi: 10.1016/j.bbi.2014.06.013. X-124973728
2610 Mitchell C, Holdt N. The search for a timely diagnosis: parents’ experiences of their child being diagnosed with an Autistic Spectrum Disorder. J Child Adolesc Ment Health. 2014;26(1):49–62. doi: 10.2989/17280583.2013.849606. X-125391570
2611 Mito H, Matsuura N, Mukai K, . The impacts of elevated autism spectrum disorder traits on clinical and psychosocial features and long-term treatment outcome in adult patients with obsessive-compulsive disorder. Compr Psychiatry. 2014 Oct;55(7):1526–33. doi: 10.1016/j.comppsych.2014.05.005. X-124957957
2612 Mizen CS. Narcissistic disorder and the failure of symbolisation: a Relational Affective Hypothesis. Med Hypotheses. 2014 Sep;83(3):254–62. doi: 10.1016/j.mehy.2014.05.012. X-124986704
2613 Mohammadzaheri F, Koegel LK, Rezaee M, . A randomized clinical trial comparison between pivotal response treatment (PRT) and structured applied behavior analysis (ABA) intervention for children with autism. J Autism Dev Disord. 2014 Nov;44(11):2769–77. doi: 10.1007/s10803-014-2137-3. X-124840596
2614 Mood D, Shield A. Clinical use of the autism diagnostic observation schedule-second edition with children who are deaf. Semin Speech Lang. 2014 Nov;35(4):288–300. doi: 10.1055/s-0034-1389101. X-125321853
2615 Mostafavi Abdolmaleky H. Horizons of psychiatric genetics and epigenetics: where are we and where are we heading? Iran J Psychiatry Behav Sci. 2014 Fall;8(3):1–10. X-1
2616 Mouti A, Reddihough D, Marraffa C, . Fluoxetine for Autistic Behaviors (FAB trial): study protocol for a randomized controlled trial in children and adolescents with autism. Trials. 2014;15:230. doi: 10.1186/1745-6215-15-230. X-1, X-2, X-424934401
2617 Mukaddes NM, Tutkunkardas MD, Sari O, . Characteristics of children who lost the diagnosis of autism: a sample from istanbul, Turkey. Autism Res Treat. 2014;2014:472120. doi: 10.1155/2014/472120. X-124876961
2618 Mukherjee S, Rupani K, Dave M, . Evaluation of effectiveness of integrated intervention in autistic children. Indian J Pediatr. 2014 Apr;81(4):339–45. doi: 10.1007/s12098-013-1169-6. X-3, X-424057967
2619 Mulligan RC, Reiersen AM, Todorov AA. Attention-Deficit/Hyperactivity Disorder, Autistic Traits, and Substance Use Among Missouri Adolescents. Scand J Child Adolesc Psychiatr Psychol. 2014;2(2):86–92. X-126146608
2620 Mundalil Vasu M, Anitha A, Thanseem I, . Serum microRNA profiles in children with autism. Mol Autism. 2014;5:40. doi: 10.1186/2040-2392-5-40. X-125126405
2621 Muratori F, Narzisi A. Exploratory study describing 6 month outcomes for young children with autism who receive treatment as usual in Italy. Neuropsychiatr Dis Treat. 2014;10:577–86. doi: 10.2147/ndt.s58308. X-1, X-324748794
2622 Murphy CM, Christakou A, Daly EM, . Abnormal functional activation and maturation of fronto-striato-temporal and cerebellar regions during sustained attention in autism spectrum disorder. American Journal of Psychiatry. 2014;171(10):1107–16 10p. doi: 10.1176/appi.ajp.2014.12030352. Corporate Author: MRC AIMS Consortium. Language: English. Entry Date: 20150313. Revision Date: 20150712. Publication Type: Journal Article. X-124873905
2623 Murphy JW, Foxe JJ, Peters JB, . Susceptibility to distraction in autism spectrum disorder: probing the integrity of oscillatory alpha-band suppression mechanisms. Autism Res. 2014 Aug;7(4):442–58. doi: 10.1002/aur.1374. X-124678054
2624 Murray ML, Hsia Y, Glaser K, . Pharmacological treatments prescribed to people with autism spectrum disorder (ASD) in primary health care. Psychopharmacology (Berl). 2014 Mar;231(6):1011–21. doi: 10.1007/s00213-013-3140-7. X-123681164
2625 Murshid EZ. Diet, oral hygiene practices and dental health in autistic children in Riyadh, Saudi Arabia. Oral Health Dent Manag. 2014 Mar;13(1):91–6. X-124603923
2626 Murza KA, Nye C, Schwartz JB, . A randomized controlled trial of an inference generation strategy intervention for adults with high-functioning autism spectrum disorder. Am J Speech Lang Pathol. 2014 Aug;23(3):461–73. doi: 10.1044/2014_ajslp-13-0012. X-124687182
2627 Must A, Curtin C, Hubbard K, . Obesity Prevention for Children with Developmental Disabilities. Curr Obes Rep. 2014 Jun;3(2):156–70. doi: 10.1007/s13679-014-0098-7. X-125530916
2628 Muthusamy K, Thomas MM, George RE, . Siblings with fucosidosis. J Pediatr Neurosci. 2014 May;9(2):156–8. doi: 10.4103/1817-1745.139331. X-125250075
2629 Nagashima M, Monden Y, Dan I, . Neuropharmacological effect of atomoxetine on attention network in children with attention deficit hyperactivity disorder during oddball paradigms as assessed using functional near-infrared spectroscopy. Neurophotonics. 2014 Oct;1(2):025007. doi: 10.1117/1.NPh.1.2.025007. X-126157979
2630 Nair MK, Lakshmi MA, Latha S, . CDC Kerala 15: Developmental Evaluation Clinic (2–10 y)--developmental diagnosis and use of home intervention package. Indian J Pediatr. 2014 Dec;81(Suppl 2):S142–50. doi: 10.1007/s12098-014-1587-0. X-1, X-325326156
2631 Nair MK, Mini AO, Leena ML, . CDC Kerala 7: Effect of early language intervention among children 0–3 y with speech and language delay. Indian J Pediatr. 2014 Dec;81(Suppl 2):S102–9. doi: 10.1007/s12098-014-1555-8. X-125179239
2632 Nair MK, Russell PS, George B, . CDC Kerala 9: Effectiveness of low intensity home based early intervention for autism spectrum disorder in India. Indian J Pediatr. 2014 Dec;81(Suppl 2):S115–9. doi: 10.1007/s12098-014-1474-8. X-325141828
2633 Nair MK, Russell PS, George B, . CDC Kerala 10: Diagnostic accuracy of the severity scores for childhood autism rating scale in India. Indian J Pediatr. 2014 Dec;81(Suppl 2):S120–4. doi: 10.1007/s12098-014-1623-0. X-125408269
2634 Nair MK, Russell PS, George B, . CDC Kerala 8: Effectiveness of a clinic based, low intensity, early intervention for children with autism spectrum disorder in India: a naturalistic observational study. Indian J Pediatr. 2014 Dec;81(Suppl 2):S110–4. doi: 10.1007/s12098-014-1601-6. X-325366289
2635 Nakako T, Murai T, Ikejiri M, . Effects of lurasidone on ketamine-induced joint visual attention dysfunction as a possible disease model of autism spectrum disorders in common marmosets. Behav Brain Res. 2014 Nov 1;274:349–54. doi: 10.1016/j.bbr.2014.08.032. X-125169254
2636 Nakamura T, Oinuma T. Usefulness of Photodynamic Diagnosis and Therapy using Talaporfin Sodium for an Advanced-aged Patient with Inoperable Gastric Cancer (a secondary publication). Laser Ther. 2014 Sep 30;23(3):201–10. doi: 10.5978/islsm.14-OR-16. X-125368446
2637 Naviaux JC, Schuchbauer MA, Li K, . Reversal of autism-like behaviors and metabolism in adult mice with single-dose antipurinergic therapy. Transl Psychiatry. 2014;4:e400. doi: 10.1038/tp.2014.33. X-124937094
2638 Nayfack AM, Huffman LC, Feldman HM, . Hospitalizations of children with autism increased from 1999 to 2009. J Autism Dev Disord. 2014 May;44(5):1087–94. doi: 10.1007/s10803-013-1965-x. X-124122446
2639 Nicely TA, Lane-Loney S, Masciulli E, . Prevalence and characteristics of avoidant/restrictive food intake disorder in a cohort of young patients in day treatment for eating disorders. J Eat Disord. 2014;2(1):21. doi: 10.1186/s40337-014-0021-3. X-125165558
2640 Nicolaidis C, Kripke CC, Raymaker D. Primary care for adults on the autism spectrum. Medical Clinics of North America. 2014;98(5):1169–91 23p. doi: 10.1016/j.mcna.2014.06.011. Language: English. Entry Date: 20141024. Revision Date: 20150712. Publication Type: Journal Article. Journal Subset: Biomedical. X-125134878
2641 Nomura K, Okada K, Noujima Y, . A clinical study of attention-deficit/hyperactivity disorder in preschool children--prevalence and differential diagnoses. Brain Dev. 2014 Oct;36(9):778–85. doi: 10.1016/j.braindev.2013.11.004. X-124295540
2642 Nyffeler J, Walitza S, Bobrowski E, . Association study in siblings and case-controls of serotonin- and oxytocin-related genes with high functioning autism. J Mol Psychiatry. 2014;2(1):1. doi: 10.1186/2049-9256-2-1. X-125408912
2643 Nyp SS, Nadler CB, Call CR, . Driven by evidence: diagnosis and treatment for children with autism spectrum disorders. Mo Med. 2014 May–Jun;111(3):195–8. X-125011339
2644 Oberman LM, Enticott PG, Casanova MF, . Transcranial magnetic stimulation (TMS) therapy for autism: an international consensus conference held in conjunction with the international meeting for autism research on May 13th and 14th, 2014. Front Hum Neurosci. 2014;8:1034. doi: 10.3389/fnhum.2014.01034. X-1, X-2, X-325642178
2645 Oberman LM, Pascual-Leone A. Hyperplasticity in Autism Spectrum Disorder confers protection from Alzheimer’s disease. Med Hypotheses. 2014 Sep;83(3):337–42. doi: 10.1016/j.mehy.2014.06.008. X-125047996
2646 Oberman LM, Pascual-Leone A, Rotenberg A. Modulation of corticospinal excitability by transcranial magnetic stimulation in children and adolescents with autism spectrum disorder. Front Hum Neurosci. 2014;8:627. doi: 10.3389/fnhum.2014.00627. X-1, X-325165441
2647 Odom SL, Thompson JL, Hedges S, . Technology-Aided Interventions and Instruction for Adolescents with Autism Spectrum Disorder. J Autism Dev Disord. 2014 Dec 3 doi: 10.1007/s10803-014-2320-6. X-1, X-2
2648 Ogawa LM, Vallender EJ. Evolutionary conservation in genes underlying human psychiatric disorders. Front Hum Neurosci. 2014;8:283. doi: 10.3389/fnhum.2014.00283. X-124834046
2649 O’Haire ME, McKenzie SJ, McCune S, . Effects of classroom animal-assisted activities on social functioning in children with autism spectrum disorder. J Altern Complement Med. 2014 Mar;20(3):162–8. doi: 10.1089/acm.2013.0165. X-124156772
2650 Olu-Lafe O, Liederman J, Tager-Flusberg H. Is the Ability to Integrate Parts into Wholes Affected in Autism Spectrum Disorder? Journal of Autism & Developmental Disorders. 2014;44(10):2652–60 9p. doi: 10.1007/s10803-014-2120-z. Language: English. Entry Date: 20140922. Revision Date: 20151001. Publication Type: Journal Article. X-124737003
2651 Oner P, Oner O, Munir K. Three-item Direct Observation Screen (TIDOS) for autism spectrum disorder. Autism. 2014 Aug;18(6):733–42. doi: 10.1177/1362361313487028. X-124126869
2652 Ong D, Chua NH, Vissers K. Percutaneous Disc Decompression for Lumbar Radicular Pain: A Review Article. Pain Pract. 2014 Oct 29 doi: 10.1111/papr.12250. X-1
2653 O’Nions E, Viding E, Greven CU, . Pathological demand avoidance: exploring the behavioural profile. Autism. 2014 Jul;18(5):538–44. doi: 10.1177/1362361313481861. X-124104509
2654 Orekhova EV, Elsabbagh M, Jones EJ, . EEG hyper-connectivity in high-risk infants is associated with later autism. J Neurodev Disord. 2014;6(1):40. doi: 10.1186/1866-1955-6-40. X-125400705
2655 Orellana LM, Martinez-Sanchis S, Silvestre FJ. Training adults and children with an autism spectrum disorder to be compliant with a clinical dental assessment using a TEACCH-based approach. J Autism Dev Disord. 2014 Apr;44(4):776–85. doi: 10.1007/s10803-013-1930-8. X-1, X-324002415
2656 Orinstein AJ, Helt M, Troyb E, . Intervention for optimal outcome in children and adolescents with a history of autism. J Dev Behav Pediatr. 2014 May;35(4):247–56. doi: 10.1097/dbp.0000000000000037. X-124799263
2657 Ouyang L, Grosse SD, Riley C, . A comparison of family financial and employment impacts of fragile X syndrome, autism spectrum disorders, and intellectual disability. Res Dev Disabil. 2014 Jul;35(7):1518–27. doi: 10.1016/j.ridd.2014.04.009. X-124755230
2658 Pahnke J, Lundgren T, Hursti T, . Outcomes of an acceptance and commitment therapy-based skills training group for students with high-functioning autism spectrum disorder: a quasi-experimental pilot study. Autism. 2014 Nov;18(8):953–64. doi: 10.1177/1362361313501091. X-124142796
2659 Paloyelis Y, Doyle OM, Zelaya FO, . A Spatiotemporal Profile of In Vivo Cerebral Blood Flow Changes Following Intranasal Oxytocin in Humans. Biol Psychiatry. 2014 Oct 18 doi: 10.1016/j.biopsych.2014.10.005. X-1
2660 Pan C-Y. Motor proficiency and physical fitness in adolescent males with and without autism spectrum disorders. Autism: The International Journal of Research & Practice. 2014;18(2):156–65 10p. doi: 10.1177/1362361312458597. Language: English. Entry Date: 20140128. Revision Date: 20150710. Publication Type: Journal Article. X-122987891
2661 Panerai S, Tasca D, Lanuzza B, . Effects of repetitive transcranial magnetic stimulation in performing eye-hand integration tasks: four preliminary studies with children showing low-functioning autism. Autism. 2014 Aug;18(6):638–50. doi: 10.1177/1362361313495717. X-1, X-324113340
2662 Panerai S, Tasca D, Lanuzza B, . Effects of repetitive transcranial magnetic stimulation in performing eye–hand integration tasks: Four preliminary studies with children showing low-functioning autism. Autism: The International Journal of Research & Practice. 2014;18(6):638–50 13p. doi: 10.1177/1362361313495717. Language: English. Entry Date: 20140723. Revision Date: 20150710. Publication Type: Journal Article. X-124113340
2663 Park MJ, Aja S, Li Q, . Anaplerotic triheptanoin diet enhances mitochondrial substrate use to remodel the metabolome and improve lifespan, motor function, and sociability in MeCP2-null mice. PLoS One. 2014;9(10):e109527. doi: 10.1371/journal.pone.0109527. X-125299635
2664 Parkinson J. Gender dysphoria in Asperger’s syndrome: a caution. Australas Psychiatry. 2014 Feb;22(1):84–5. doi: 10.1177/1039856213497814. X-123897727
2665 Pasalich DS, Dadds MR, Hawes DJ. Cognitive and affective empathy in children with conduct problems: additive and interactive effects of callous-unemotional traits and autism spectrum disorders symptoms. Psychiatry Res. 2014 Nov 30;219(3):625–30. doi: 10.1016/j.psychres.2014.06.025. X-125015711
2666 Pasco G, Clark B, Dragan I, . A training and development project to improve services and opportunities for social inclusion for children and young people with autism in Romania. Autism. 2014 Oct;18(7):827–31. doi: 10.1177/1362361314524642. X-124590469
2667 Pasiali V, LaGasse AB, Penn SL. The effect of musical attention control training (MACT) on attention skills of adolescents with neurodevelopmental delays: a pilot study. J Music Ther. 2014 Winter;51(4):333–54. doi: 10.1093/jmt/thu030. X-125504177
2668 Payakachat N, Tilford JM, Kuhlthau KA, . Predicting health utilities for children with autism spectrum disorders. Autism Res. 2014 Dec;7(6):649–63. doi: 10.1002/aur.1409. X-125255789
2669 Pedersen L, Parlar S, Kvist K, . Data mining the ScanBrit study of a gluten-and casein-free dietary intervention for children with autism spectrum disorders: behavioural and psychometric measures of dietary response. Nutr Neurosci. 2014 Sep;17(5):207–13. doi: 10.1179/1476830513y.0000000082.24075141
2670 Pennington ML, Cullinan D, Southern LB. Defining autism: variability in state education agency definitions of and evaluations for autism spectrum disorders. Autism Res Treat. 2014;2014:327271. doi: 10.1155/2014/327271. X-124987527
2671 Perron L. [Art therapy to support autistic people]. Soins Pediatr Pueric. 2014 Jan–Feb(276):36–8. X-1, X-2, X-3
2672 Petersen DB, Brown CL, Ukrainetz TA, . Systematic individualized narrative language intervention on the personal narratives of children with autism. Lang Speech Hear Serv Sch. 2014 Jan;45(1):67–86. doi: 10.1044/2013_lshss-12-0099. X-3, X-424687768
2673 Petersen I, Evans S, Nazareth I. Prenatal exposure to selective serotonin reuptake inhibitors and autistic symptoms in young children: another red herring? Br J Psychiatry. 2014 Aug;205(2):105–6. doi: 10.1192/bjp.bp.113.141721. X-125252319
2674 Phillips KL, Schieve LA, Visser S, . Prevalence and impact of unhealthy weight in a national sample of US adolescents with autism and other learning and behavioral disabilities. Matern Child Health J. 2014 Oct;18(8):1964–75. doi: 10.1007/s10995-014-1442-y. X-124553796
2675 Pickles A, Anderson DK, Lord C. Heterogeneity and plasticity in the development of language: a 17-year follow-up of children referred early for possible autism. J Child Psychol Psychiatry. 2014 Dec;55(12):1354–62. doi: 10.1111/jcpp.12269. X-124889883
2676 Pifer R, Sperandio V. The Interplay between the Microbiota and Enterohemorrhagic Escherichia coli. Microbiol Spectr. 2014 Oct;2(5) doi: 10.1128/microbiolspec.EHEC-0015-2013. X-1
2677 Pillai D, Sheppard E, Ropar D, . Using Other Minds as a Window Onto the World: Guessing What Happened from Clues in Behaviour. Journal of Autism & Developmental Disorders. 2014;44(10):2430–9 10p. doi: 10.1007/s10803-014-2106-x. Language: English. Entry Date: 20140922. Revision Date: 20151001. Publication Type: Journal Article. X-124710812
2678 Pineda JA, Carrasco K, Datko M, . Neurofeedback training produces normalization in behavioural and electrophysiological measures of high-functioning autism. Philos Trans R Soc Lond B Biol Sci. 2014;369(1644):20130183. doi: 10.1098/rstb.2013.0183. X-3, X-424778378
2679 Pineda JA, Friedrich EV, LaMarca K. Neurorehabilitation of social dysfunctions: a model-based neurofeedback approach for low and high-functioning autism. Front Neuroeng. 2014;7:29. doi: 10.3389/fneng.2014.00029. X-1, X-225147521
2680 Pini G, Scusa MF, Benincasa A, . Repeated insulin-like growth factor 1 treatment in a patient with rett syndrome: a single case study. Front Pediatr. 2014;2:52. doi: 10.3389/fped.2014.00052. X-124918098
2681 Poot M. A candidate gene association study further corroborates involvement of contactin genes in autism. Mol Syndromol. 2014 Aug;5(5):229–35. doi: 10.1159/000362891. X-125337070
2682 Pop-Jordanova N, Plasevska-Karanfilska D. Autism - genetics, electrophysiology and clinical syndromes. Prilozi. 2014;35(1):133–46. X-124802198
2683 Poslawsky IE, Naber FB, Bakermans-Kranenburg MJ, . Development of a Video-feedback Intervention to promote Positive Parenting for Children with Autism (VIPP-AUTI). Attach Hum Dev. 2014;16(4):343–55. doi: 10.1080/14616734.2014.912487. X-124972103
2684 Poslawsky IE, Naber FB, Van Daalen E, . Parental reaction to early diagnosis of their children’s autism spectrum disorder: an exploratory study. Child Psychiatry Hum Dev. 2014 Jun;45(3):294–305. doi: 10.1007/s10578-013-0400-z. X-123959534
2685 Post M, Haymes L, Storey K, . Understanding stalking behaviors by individuals with Autism Spectrum Disorders and recommended prevention strategies for school settings. J Autism Dev Disord. 2014 Nov;44(11):2698–706. doi: 10.1007/s10803-012-1712-8. X-1, X-2, X-323207743
2686 Pozo P, Sarria E. Prediction of stress in mothers of children with autism spectrum disorders. Span J Psychol. 2014;17:E6. doi: 10.1017/sjp.2014.6. X-125012691
2687 Pragnya B, Kameshwari JS, Veeresh B. Ameliorating effect of piperine on behavioral abnormalities and oxidative markers in sodium valproate induced autism in BALB/C mice. Behav Brain Res. 2014 Aug 15;270:86–94. doi: 10.1016/j.bbr.2014.04.045. X-124803211
2688 Prast JM, Schardl A, Schwarzer C, . Reacquisition of cocaine conditioned place preference and its inhibition by previous social interaction preferentially affect D1-medium spiny neurons in the accumbens corridor. Front Behav Neurosci. 2014;8:317. doi: 10.3389/fnbeh.2014.00317. X-125309368
2689 Preis J, McKenna M. The effects of sensory integration therapy on verbal expression and engagement in children with autism. International Journal of Therapy & Rehabilitation. 2014;21(10):476–86 11p. Language: English. Entry Date: 20141119. Revision Date: 20150820. Publication Type: Journal Article. X-1, X-3, X-4
2690 Pretto D, Yrigollen CM, Tang HT, . Clinical and molecular implications of mosaicism in FMR1 full mutations. Front Genet. 2014;5:318. doi: 10.3389/fgene.2014.00318. X-125278957
2691 Price AM, Coates C, Symeonides C, . Chocolate frogs do not increase completion of parent survey: randomised study. J Paediatr Child Health. 2014 Nov;50(11):866–8. doi: 10.1111/jpc.12606. X-124925605
2692 Provenzano G, Clementi E, Genovesi S, . GH Dysfunction in Engrailed-2 Knockout Mice, a Model for Autism Spectrum Disorders. Front Pediatr. 2014;2:92. doi: 10.3389/fped.2014.00092. X-125225635
2693 Puckering C, Allely CS, Doolin O, . Association between parent-infant interactions in infancy and disruptive behaviour disorders at age seven: a nested, case-control ALSPAC study. BMC Pediatr. 2014;14:223. doi: 10.1186/1471-2431-14-223. X-125193601
2694 Puertas-Martin V, Carreras-Saez I, Marana A, . [Therapeutic possibilities in refractory epilepsy in tuberous sclerosis complex]. Rev Neurol. 2014 Jun 16;58(12):529–35. X-124915028
2695 Pugliese CE, White SW. Brief report: problem solving therapy in college students with autism spectrum disorders: feasibility and preliminary efficacy. J Autism Dev Disord. 2014 Mar;44(3):719–29. doi: 10.1007/s10803-013-1914-8. X-123963592
2696 Puscian A, Leski S, Gorkiewicz T, . A novel automated behavioral test battery assessing cognitive rigidity in two genetic mouse models of autism. Front Behav Neurosci. 2014;8:140. doi: 10.3389/fnbeh.2014.00140. X-124808839
2697 Radell ML, Mercado E, 3rd. Modeling possible effects of atypical cerebellar processing on eyeblink conditioning in autism. Cogn Affect Behav Neurosci. 2014 Sep;14(3):1142–64. doi: 10.3758/s13415-014-0263-1. X-124590391
2698 Raduege TJ. Benefits and services. Issue Brief Health Policy Track Serv. 2014 Dec 29:1–51. X-5
2699 Raggi A, Meucci P, Leonardi M, . The development of a structured schedule for collecting ICF-CY-based information on disability in school and preschool children: an action research from Italy. Int J Rehabil Res. 2014 Mar;37(1):86–96. doi: 10.1097/mrr.0000000000000042. X-124323140
2700 Rahbar MH, Samms-Vaughan M, Dickerson AS, . Role of fruits, grains, and seafood consumption in blood cadmium concentrations of Jamaican children with and without Autism Spectrum Disorder. Res Autism Spectr Disord. 2014 Sep 1;8(9):1134–45. doi: 10.1016/j.rasd.2014.06.002. X-125089152
2701 Rahman FR, Maharaj V, Yates R, . Addressing the inverse care law: the role of community paediatric services. Perspect Public Health. 2014 Mar;134(2):85–92. doi: 10.1177/1757913913516089. X-124406636
2702 Raja S, Mohapatra S, Kumar JS, . Prescription patterns of hypolipidaemic drugs in a tertiary care teaching hospital of southern India. J Clin Diagn Res. 2014 Apr;8(4):Hc01–3. doi: 10.7860/jcdr/2014/8010.4206. X-1
2703 Rance G, Saunders K, Carew P, . The use of listening devices to ameliorate auditory deficit in children with autism. J Pediatr. 2014 Feb;164(2):352–7. doi: 10.1016/j.jpeds.2013.09.041. X-1, X-324183205
2704 Rattaz C, Ledesert B, Masson O, . Special education and care services for children, adolescents, and adults with autism spectrum disorders in France: Families’ opinion and satisfaction. Autism. 2014 Feb;18(2):185–93. doi: 10.1177/1362361312460952. X-123045217
2705 Rattazzi A. [The importance of early detection and early intervention for children with autism spectrum conditions]. Vertex. 2014 Jul–Aug;25(116):290–4. X-125546644
2706 Rauf NK, Anis ul H, Aslam N, . Characteristic symptoms and adaptive behaviors of children with autism. J Coll Physicians Surg Pak. 2014 Sep;24(9):658–62. X-125233971
2707 Reading R. Psychotropic medication use and polypharmacy in children with autism spectrum disorders. Child: Care, Health & Development. 2014;40(1):147–8 2p. doi: 10.1111/cch.12123_6. Language: English. Entry Date: 20131203. Revision Date: 20150711. Publication Type: Journal Article. X-1, X-2, X-3
2708 Regent L. [Bibliography. Autism in childhood and adolescence]. Soins Pediatr Pueric. 2014 Jan–Feb(276):39. X-1
2709 Retico A, Tosetti M, Muratori F, . Neuroimaging-based methods for autism identification: a possible translational application? Funct Neurol. 2014 Oct–Dec;29(4):231–9. X-125764253
2710 Rhind C, Bonfioli E, Hibbs R, . An examination of autism spectrum traits in adolescents with anorexia nervosa and their parents. Mol Autism. 2014;5(1):56. doi: 10.1186/2040-2392-5-56. X-125553237
2711 Richdale AL, Baker E, Short M, . The role of insomnia, pre-sleep arousal and psychopathology symptoms in daytime impairment in adolescents with high-functioning autism spectrum disorder. Sleep Med. 2014 Sep;15(9):1082–8. doi: 10.1016/j.sleep.2014.05.005. X-124974199
2712 Rideau Batista Novais A, Crouzin N, Cavalier M, . Tiagabine improves hippocampal long-term depression in rat pups subjected to prenatal inflammation. PLoS One. 2014;9(9):e106302. doi: 10.1371/journal.pone.0106302. X-125184226
2713 Rieffe C, De Bruine M, De Rooij M, . Approach and avoidant emotion regulation prevent depressive symptoms in children with an Autism Spectrum Disorder. Int J Dev Neurosci. 2014 Dec;39:37–43. doi: 10.1016/j.ijdevneu.2014.06.003. X-1, X-324951836
2714 Righi G, Tierney AL, Tager-Flusberg H, . Functional connectivity in the first year of life in infants at risk for autism spectrum disorder: an EEG study. PLoS One. 2014;9(8):e105176. doi: 10.1371/journal.pone.0105176. X-125140874
2715 Rispoli M, Camargo S, Machalicek W, . Functional communication training in the treatment of problem behavior maintained by access to rituals. J Appl Behav Anal. 2014 Fall;47(3):580–93. doi: 10.1002/jaba.130. X-3, X-424817482
2716 Rispoli M, Camargo SH, Neely L, . Pre-Session Satiation as a Treatment for Stereotypy During Group Activities. Behav Modif. 2014 May;38(3):392–411. doi: 10.1177/0145445513511631. X-124270401
2717 Roane HS, DeRosa NM. Reduction of emergent dropping behavior during treatment of elopement. J Appl Behav Anal. 2014 Fall;47(3):633–8. doi: 10.1002/jaba.136. X-1, X-3, X-424825372
2718 Robertson CE, Thomas C, Kravitz DJ, . Global motion perception deficits in autism are reflected as early as primary visual cortex. Brain: A Journal of Neurology. 2014;137(9):2588–99 12p. doi: 10.1093/brain/awu189. Language: English. Entry Date: 20141121. Revision Date: 20150901. Publication Type: Journal Article. Journal Subset: Allied Health. X-125060095
2719 Rogers SJ, Vismara L, Wagner AL, . Autism treatment in the first year of life: a pilot study of infant start, a parent-implemented intervention for symptomatic infants. J Autism Dev Disord. 2014 Dec;44(12):2981–95. doi: 10.1007/s10803-014-2202-y. X-1, X-425212413
2720 Rosales R, Maderitz C, Garcia YA. Comparison of simple and complex auditory-visual conditional discrimination training. J Appl Behav Anal. 2014 Summer;47(2):437–42. doi: 10.1002/jaba.121. X-1, X-3, X-424764261
2721 Rossman IT, Lin L, Morgan KM, . Engrailed2 modulates cerebellar granule neuron precursor proliferation, differentiation and insulin-like growth factor 1 signaling during postnatal development. Mol Autism. 2014;5(1):9. doi: 10.1186/2040-2392-5-9. X-124507165
2722 Ruiz-Robledillo N, Gonzalez-Bono E, Moya-Albiol L. Lack of institutional support entails disruption in cortisol awakening response in caregivers of people with high-functioning autism. J Health Psychol. 2014 Dec;19(12):1586–96. doi: 10.1177/1359105313496444. X-123933951
2723 Russo A. Decreased Mitogen Inducible Gene 6 (MIG-6) Associated with Symptom Severity in Children with Autism. Biomark Insights. 2014;9:85–9. doi: 10.4137/bmi.s15218. X-125342879
2724 Russo AJ. Increased Epidermal Growth Factor Receptor (EGFR) Associated with Hepatocyte Growth Factor (HGF) and Symptom Severity in Children with Autism Spectrum Disorders (ASDs). J Cent Nerv Syst Dis. 2014;6:79–83. doi: 10.4137/jcnsd.s13767. X-125249767
2725 Sadoughi HR, Nasseri S, Momennezhad M, . A Comparison Between GATE and MCNPX Monte Carlo Codes in Simulation of Medical Linear Accelerator. J Med Signals Sens. 2014 Jan;4(1):10–7. X-124696804
2726 Saloviita T, Leppanen M, Ojalammi U. Authorship in facilitated communication: an analysis of 11 cases. Augment Altern Commun. 2014 Sep;30(3):213–25. doi: 10.3109/07434618.2014.927529. X-124946681
2727 Samadi SA, McConkey R. The utility of the Gilliam autism rating scale for identifying Iranian children with autism. Disabil Rehabil. 2014;36(6):452–6. doi: 10.3109/09638288.2013.797514. X-123738615
2728 Samaras K, Correll CU, Mitchell AJ, . Diabetes risk potentially underestimated in youth and children receiving antipsychotics. JAMA Psychiatry. 2014 Feb;71(2):209–10. doi: 10.1001/jamapsychiatry.2013.4030. X-124500630
2729 San Mauro Martin I, Garicano Vilar E, Collado Yurrutia L, . [Is gluten the great etiopathogenic agent of disease in the XXI century?]. Nutr Hosp. 2014;30(6):1203–10. doi: 10.3305/nh.2014.30.6.7866. X-125433099
2730 Sangha S, Greba Q, Robinson PD, . Heightened fear in response to a safety cue and extinguished fear cue in a rat model of maternal immune activation. Front Behav Neurosci. 2014;8:168. doi: 10.3389/fnbeh.2014.00168. X-124847231
2731 Sato W, Kubota Y, Kochiyama T, . Increased putamen volume in adults with autism spectrum disorder. Front Hum Neurosci. 2014;8:957. doi: 10.3389/fnhum.2014.00957. X-125505401
2732 Savoy M. Autism: 5 misconceptions that can complicate care. J Fam Pract. 2014 Jun;63(6):310–4. X-125061620
2733 Scaler Scott K, Tetnowski JA, Flaitz JR, . Preliminary study of disfluency in school-aged children with autism. Int J Lang Commun Disord. 2014 Jan–Feb;49(1):75–89. doi: 10.1111/1460-6984.12048. X-124372887
2734 Schaaf RC, Leiby B, Benevides T, . Response from authors to comments on “An intervention for sensory difficulties in children with autism: A randomized trial”. Journal of Autism and Developmental Disorders. 2014 2015-02-24;44(6):1489–91. doi: 10.1016/j.rasd.2006.08.006 doi: 10.1016/j.rasd.2008.11.001. http://dx.doi.org/10.1007/s10803-014-2111-0; 2014-20681-001. X-1, X-224722761
2735 Schafer EC, Bryant D, Sanders K, . Fitting and verification of frequency modulation systems on children with normal hearing. J Am Acad Audiol. 2014 Jun;25(6):529–40. doi: 10.3766/jaaa.25.6.3. X-125313543
2736 Scheele D, Kendrick KM, Khouri C, . An oxytocin-induced facilitation of neural and emotional responses to social touch correlates inversely with autism traits. Neuropsychopharmacology. 2014 Aug;39(9):2078–85. doi: 10.1038/npp.2014.78. X-124694924
2737 Schelinski S, Riedel P, von Kriegstein K. Visual abilities are important for auditory-only speech recognition: evidence from autism spectrum disorder. Neuropsychologia. 2014 Dec;65:1–11. doi: 10.1016/j.neuropsychologia.2014.09.031. X-125283605
2738 Schieve LA, Tian LH, Baio J, . Population attributable fractions for three perinatal risk factors for autism spectrum disorders, 2002 and 2008 autism and developmental disabilities monitoring network. Ann Epidemiol. 2014 Apr;24(4):260–6. doi: 10.1016/j.annepidem.2013.12.014. X-124529515
2739 Schindel RH, Chahine A, Anderson N, . Behavior modification of children with autism spectrum disorder in an orthodontic setting. J Clin Orthod. 2014 May;48(5):285–91. X-525083672
2740 Schlosser RW, Koul R, Shane H, . Effects of animation on naming and identification across two graphic symbol sets representing verbs and prepositions. J Speech Lang Hear Res. 2014 Oct;57(5):1779–91. doi: 10.1044/2014_jslhr-l-13-0193. X-1, X-324811580
2741 Schmidt RJ, Tancredi DJ, Krakowiak P, . Maternal intake of supplemental iron and risk of autism spectrum disorder. Am J Epidemiol. 2014 Nov 1;180(9):890–900. doi: 10.1093/aje/kwu208. X-125249546
2742 Schmitt LM, Cook EH, Sweeney JA, . Saccadic eye movement abnormalities in autism spectrum disorder indicate dysfunctions in cerebellum and brainstem. Mol Autism. 2014;5(1):47. doi: 10.1186/2040-2392-5-47. X-125400899
2743 Schoen Simmons E, Paul R, Volkmar F. Assessing pragmatic language in autism spectrum disorder: the Yale in vivo Pragmatic Protocol. J Speech Lang Hear Res. 2014 Dec;57(6):2162–73. doi: 10.1044/2014_jslhr-l-14-0040. X-125029348
2744 Schohl KA, Van Hecke AV, Carson AM, . A replication and extension of the PEERS intervention: examining effects on social skills and social anxiety in adolescents with autism spectrum disorders. J Autism Dev Disord. 2014 Mar;44(3):532–45. doi: 10.1007/s10803-013-1900-1. X-123893101
2745 Schore AN. Early interpersonal neurobiological assessment of attachment and autistic spectrum disorders. Front Psychol. 2014;5:1049. doi: 10.3389/fpsyg.2014.01049. X-125339916
2746 Schreibman L, Stahmer AC. A randomized trial comparison of the effects of verbal and pictorial naturalistic communication strategies on spoken language for young children with autism. J Autism Dev Disord. 2014 May;44(5):1244–51. doi: 10.1007/s10803-013-1972-y. X-124272416
2747 Schubart JR, Camacho F, Leslie D. Psychotropic medication trends among children and adolescents with autism spectrum disorder in the Medicaid program. Autism. 2014 Aug;18(6):631–7. doi: 10.1177/1362361313497537. X-124165274
2748 Schuwerk T, Langguth B, Sommer M. Modulating functional and dysfunctional mentalizing by transcranial magnetic stimulation. Front Psychol. 2014;5:1309. doi: 10.3389/fpsyg.2014.01309. X-125477838
2749 Segal O, Kaplan D, Patael S, . Judging emotions in lexical-prosodic congruent and incongruent speech stimuli by adolescents in the autism spectrum. Folia Phoniatr Logop. 2014;66(1–2):25–36. doi: 10.1159/000363739. X-125472790
2750 Segovia F, Holt R, Spencer M, . Identifying endophenotypes of autism: a multivariate approach. Front Comput Neurosci. 2014;8:60. doi: 10.3389/fncom.2014.00060. X-124936183
2751 Sener EF, Oztop DB, Ozkul Y. MTHFR Gene C677T Polymorphism in Autism Spectrum Disorders. Genet Res Int. 2014;2014:698574. doi: 10.1155/2014/698574. X-125431675
2752 Serret S, Hun S, Iakimova G, . Facing the challenge of teaching emotions to individuals with low- and high-functioning autism using a new Serious game: a pilot study. Mol Autism. 2014;5:37. doi: 10.1186/2040-2392-5-37. X-325018866
2753 Shaddel F, Ghazirad M, Bryant M. What is the best available evidence for using homeopathy in patients with intellectual disabilities? Iran J Pediatr. 2014 Aug;24(4):339–44. X-1, X-2, X-325755852
2754 Shafai T, Mustafa M, Hild T, . The association of early weaning and formula feeding with autism spectrum disorders. Breastfeed Med. 2014 Jun;9(5):275–6. doi: 10.1089/bfm.2013.0104. X-124506526
2755 Sharda M, Khundrakpam BS, Evans AC, . Disruption of structural covariance networks for language in autism is modulated by verbal ability. Brain Struct Funct. 2014 Dec 2 doi: 10.1007/s00429-014-0953-z. X-1
2756 Sharp WG, Burrell TL, Jaquess DL. The Autism MEAL Plan: a parent-training curriculum to manage eating aversions and low intake among children with autism. Autism. 2014 Aug;18(6):712–22. doi: 10.1177/1362361313489190. X-424101716
2757 Shattuck PT, Steinberg J, Yu J, . Disability Identification and Self-Efficacy among College Students on the Autism Spectrum. Autism Res Treat. 2014;2014:924182. doi: 10.1155/2014/924182. X-124707401
2758 Sherif T, Rioux P, Rousseau ME, . CBRAIN: a web-based, distributed computing platform for collaborative neuroimaging research. Front Neuroinform. 2014;8:54. doi: 10.3389/fninf.2014.00054. X-124904400
2759 Shield A. Preliminary findings of similarities and differences in the signed and spoken language of children with autism. Semin Speech Lang. 2014 Nov;35(4):309–20. doi: 10.1055/s-0034-1389103. X-125321855
2760 Shih W, Patterson SY, Kasari C. Developing an Adaptive Treatment Strategy for Peer-Related Social Skills for Children With Autism Spectrum Disorders. J Clin Child Adolesc Psychol. 2014 Jun 13:1–11. doi: 10.1080/15374416.2014.915549. X-1
2761 Shrestha M, Shrestha R. Symptom recognition to diagnosis of autism in Nepal. J Autism Dev Disord. 2014 Jun;44(6):1483–5. doi: 10.1007/s10803-013-2005-6. X-124293038
2762 Siegel M, Beresford CA, Bunker M, . Preliminary investigation of lithium for mood disorder symptoms in children and adolescents with autism spectrum disorder. J Child Adolesc Psychopharmacol. 2014 Sep;24(7):399–402. doi: 10.1089/cap.2014.0019. X-125093602
2763 Siegel M, Milligan B, Chemelski B, . Specialized inpatient psychiatry for serious behavioral disturbance in autism and intellectual disability. J Autism Dev Disord. 2014 Dec;44(12):3026–32. doi: 10.1007/s10803-014-2157-z. X-324925543
2764 Siller M, Reyes N, Hotez E, . Longitudinal change in the use of services in autism spectrum disorder: understanding the role of child characteristics, family demographics, and parent cognitions. Autism. 2014 May;18(4):433–46. doi: 10.1177/1362361313476766. X-124108191
2765 Siller M, Swanson M, Gerber A, . A parent-mediated intervention that targets responsive parental behaviors increases attachment behaviors in children with ASD: results from a randomized clinical trial. J Autism Dev Disord. 2014 Jul;44(7):1720–32. doi: 10.1007/s10803-014-2049-2. X-124488157
2766 Silverman L, Hollway JA, Smith T, . A Multisite Trial of Atomoxetine and Parent Training in Children with Autism Spectrum Disorders: Rationale and Design Challenges. Res Autism Spectr Disord. 2014 Jul 1;8(7):899–907. doi: 10.1016/j.rasd.2014.03.013. X-125197320
2767 Singh K, Connors SL, Macklin EA, . Sulforaphane treatment of autism spectrum disorder (ASD). Proc Natl Acad Sci U S A. 2014 Oct 28;111(43):15550–5. doi: 10.1073/pnas.1416940111. X-125313065
2768 Singleton G, Warren S, Piersel W. Clinical overview of the need for technologies for around-the-clock monitoring of the health status of severely disabled autistic children. Conf Proc IEEE Eng Med Biol Soc. 2014 Aug;2014:789–91. doi: 10.1109/embc.2014.6943709. X-125570077
2769 Smith EG. Multisensory integration and temporal synchrony in autism; 2014.
2770 Smith J, Hand L, Dowrick PW. Video feedforward for rapid learning of a picture-based communication system. J Autism Dev Disord. 2014 Apr;44(4):926–36. doi: 10.1007/s10803-013-1946-0. X-1, X-3, X-424068486
2771 Smith MJ, Ginger EJ, Wright K, . Virtual reality job interview training in adults with autism spectrum disorder. J Autism Dev Disord. 2014 Oct;44(10):2450–63. doi: 10.1007/s10803-014-2113-y. X-124803366
2772 Smith T. Behavior analysts can be interdisciplinary too: a review of durand’s autism spectrum disorder. J Appl Behav Anal. 2014 Oct 17 doi: 10.1002/jaba.157. X-1
2773 Sokhadze EM, El-Baz AS, Sears LL, . rTMS neuromodulation improves electrocortical functional measures of information processing and behavioral responses in autism. Front Syst Neurosci. 2014;8:134. doi: 10.3389/fnsys.2014.00134. X-1, X-325147508
2774 Sokhadze EM, El-Baz AS, Tasman A, . Neuromodulation integrating rTMS and neurofeedback for the treatment of autism spectrum disorder: an exploratory study. Appl Psychophysiol Biofeedback. 2014 Dec;39(3–4):237–57. doi: 10.1007/s10484-014-9264-7. X-125267414
2775 Solomon R, Van Egeren LA, Mahoney G, . PLAY Project Home Consultation intervention program for young children with autism spectrum disorders: a randomized controlled trial. J Dev Behav Pediatr. 2014 Oct;35(8):475–85. doi: 10.1097/dbp.0000000000000096. X-125264862
2776 Spriggs AD, Knight V, Sherrow L. Talking Picture Schedules: Embedding Video Models into Visual Activity Schedules to Increase Independence for Students with ASD. J Autism Dev Disord. 2014 Nov 21 doi: 10.1007/s10803-014-2315-3. X-1
2777 Srinivasan SM, Pescatello LS, Bhat AN. Current Perspectives on Physical Activity and Exercise Recommendations for Children and Adolescents With Autism Spectrum Disorders. Physical Therapy. 2014;94(6):875–89 15p. doi: 10.2522/ptj.20130157. Language: English. Entry Date: 20140610. Revision Date: 20150820. Publication Type: Journal Article. X-124525861
2778 Srivastava S, Landy-Schmitt C, Clark B, . Autism traits in children and adolescents with Cornelia de Lange syndrome. Am J Med Genet A. 2014 Jun;164a(6):1400–10. doi: 10.1002/ajmg.a.36573. X-124718998
2779 Stagg SD, Slavny R, Hand C, . Does facial expressivity count? How typically developing children respond initially to children with autism. Autism. 2014 Aug;18(6):704–11. doi: 10.1177/1362361313492392. X-124121180
2780 Starovoitova TE, Dolgikh VV, Mikhnovich VI, . [Electric status epilepticus in sleep (case report).]. Zh Nevrol Psikhiatr Im S S Korsakova. 2014;114(4 Vypusk 2 Epilepsy):8–10. X-1
2781 Steeb H, Ramsey JM, Guest PC, . Serum proteomic analysis identifies sex-specific differences in lipid metabolism and inflammation profiles in adults diagnosed with Asperger syndrome. Mol Autism. 2014;5(1):4. doi: 10.1186/2040-2392-5-4. X-124467795
2782 Stein K. The politics and process of revising the DSM-V and the impact of changes on dietetics. J Acad Nutr Diet. 2014 Mar;114(3):350–65. doi: 10.1016/j.jand.2013.12.011. X-124534369
2783 Steiner NJ, Frenette E, Hynes C, . A pilot feasibility study of neurofeedback for children with autism. Appl Psychophysiol Biofeedback. 2014 Jun;39(2):99–107. doi: 10.1007/s10484-014-9241-1. X-3, X-424737038
2784 Stevenson RA, Segers M, Ferber S, . The impact of mutisensory integration deficits on speech perception in children with autism spectrum disorders. Frontiers in Psychology. 2014 2015-12-09;5 doi: 10.1093/cercor/bht213. CrossRef Medline. doi: 10.1007/s10803-010-1000-4; 2014-40502-001. X-1, X-224478738
2785 Stevenson RA, Siemann JK, Schneider BC, . Multisensory temporal integration in autism spectrum disorders. J Neurosci. 2014 Jan 15;34(3):691–7. doi: 10.1523/jneurosci.3615-13.2014. X-124431427
2786 Stevenson RA, Siemann JK, Woynaroski TG, . Evidence for diminished multisensory integration in autism spectrum disorders. J Autism Dev Disord. 2014 Dec;44(12):3161–7. doi: 10.1007/s10803-014-2179-6. X-125022248
2787 Stevenson RA, Siemann JK, Woynaroski TG, . Brief report: Arrested development of audiovisual speech perception in autism spectrum disorders. J Autism Dev Disord. 2014 Jun;44(6):1470–7. doi: 10.1007/s10803-013-1992-7. X-124218241
2788 Stichter JP, Laffey J, Galyen K, . iSocial: delivering the Social Competence Intervention for Adolescents (SCI-A) in a 3D virtual learning environment for youth with high functioning autism. J Autism Dev Disord. 2014 Feb;44(2):417–30. doi: 10.1007/s10803-013-1881-0. X-123812663
2789 Stoodley CJ. Distinct regions of the cerebellum show gray matter decreases in autism, ADHD, and developmental dyslexia. Front Syst Neurosci. 2014;8:92. doi: 10.3389/fnsys.2014.00092. X-124904314
2790 Strickland AD. Prevention of cerebral palsy, autism spectrum disorder, and attention deficit-hyperactivity disorder. Med Hypotheses. 2014 May;82(5):522–8. doi: 10.1016/j.mehy.2014.02.003. X-124581674
2791 Strifert K. The link between oral contraceptive use and prevalence in autism spectrum disorder. Med Hypotheses. 2014 Dec;83(6):718–25. doi: 10.1016/j.mehy.2014.09.026. X-125459142
2792 Strunz S, Westphal L, Ritter K, . Personality Pathology of Adults With Autism Spectrum Disorder Without Accompanying Intellectual Impairment in Comparison to Adults With Personality Disorders. J Autism Dev Disord. 2014 Jul 15 doi: 10.1007/s10803-014-2183-x. X-1
2793 Stubendorff K, Larsson V, Ballard C, . Treatment effect of memantine on survival in dementia with Lewy bodies and Parkinson’s disease with dementia: a prospective study. BMJ Open. 2014;4(7):e005158. doi: 10.1136/bmjopen-2014-005158. X-1
2794 Stuttard L, Beresford B, Clarke S, . Riding the rapids: living with autism or disability--an evaluation of a parenting support intervention for parents of disabled children. Res Dev Disabil. 2014 Oct;35(10):2371–83. doi: 10.1016/j.ridd.2014.05.021. X-124973545
2795 Sugama M, Ishizaki A. [Drug therapy for AD/HD investigation of usefulness of extended-release methylphenidate and atomoxetine from the viewpoint of persistency rate]. No To Hattatsu. 2014 Jan;46(1):22–5. X-1, X-324620426
2796 Suing M, Gollan T, Schmidt MH, . [In Process Citation]. Prax Kinderpsychol Kinderpsychiatr. 2014 Oct;63(8):666–84. doi: 10.13109/prkk.2014.63.8.666. X-125524037
2797 Sullivan JC, Miller LJ, Nielsen DM, . The presence of migraines and its association with sensory hyperreactivity and anxiety symptomatology in children with autism spectrum disorder. Autism. 2014 Aug;18(6):743–7. doi: 10.1177/1362361313489377. X-124072661
2798 Sun J, Chang EB. Exploring gut microbes in human health and disease: Pushing the envelope. Genes Dis. 2014 Dec;1(2):132–9. doi: 10.1016/j.gendis.2014.08.001. X-125642449
2799 Sun JG, Sun XR. [Encephalopathy therapeutic tongue acupoint apparatus (ETTAA) for 42 cases of autism]. Zhongguo Zhen Jiu. 2014 Jan;34(1):96–8. X-124673076
2800 Sun X, Allison C, Auyeung B, . Comparison between a Mandarin Chinese version of the Childhood Autism Spectrum Test and the Clancy Autism Behaviour Scale in mainland China. Res Dev Disabil. 2014 Jul;35(7):1599–608. doi: 10.1016/j.ridd.2014.02.005. X-124769432
2801 Suren P, Gunnes N, Roth C, . Parental obesity and risk of autism spectrum disorder. Pediatrics. 2014 May;133(5):e1128–38. doi: 10.1542/peds.2013-3664. X-124709932
2802 Suresh AP, Benjamin TE, Crasta JE, . Comparison of burden among primary care-givers of children with autism and intellectual disability against children with intellectual disability only in a hospital population in India. Indian J Pediatr. 2014 Dec;81(Suppl 2):S179–82. doi: 10.1007/s12098-014-1626-x. X-125387661
2803 Suzuki M, Yamada A, Watanabe N, . A failure to confirm the effectiveness of a brief group psychoeducational program for mothers of children with high-functioning pervasive developmental disorders: a randomized controlled pilot trial. Neuropsychiatr Dis Treat. 2014;10:1141–53. doi: 10.2147/ndt.s60058. X-125061301
2804 Swanson AR, Warren ZE, Stone WL, . The diagnosis of autism in community pediatric settings: does advanced training facilitate practice change? Autism. 2014 Jul;18(5):555–61. doi: 10.1177/1362361313481507. X-123847130
2805 Takahashi H, Nakahachi T, Komatsu S, . Hyperreactivity to weak acoustic stimuli and prolonged acoustic startle latency in children with autism spectrum disorders. Mol Autism. 2014;5(1):23. doi: 10.1186/2040-2392-5-23. X-124618368
2806 Takara K, Kondo T. Comorbid atypical autistic traits as a potential risk factor for suicide attempts among adult depressed patients: a case-control study. Ann Gen Psychiatry. 2014;13(1):33. doi: 10.1186/s12991-014-0033-z. X-125328535
2807 Takuma K, Hara Y, Kataoka S, . Chronic treatment with valproic acid or sodium butyrate attenuates novel object recognition deficits and hippocampal dendritic spine loss in a mouse model of autism. Pharmacol Biochem Behav. 2014 Nov;126:43–9. doi: 10.1016/j.pbb.2014.08.013. X-125240644
2808 Tan XY, Trembath D, Bloomberg K, . Acquisition and generalization of key word signing by three children with autism. Dev Neurorehabil. 2014 Apr;17(2):125–36. doi: 10.3109/17518423.2013.863236. X-3, X-424393060
2809 Tanidir C, Mukaddes NM. Referral pattern and special interests in children and adolescents with Asperger syndrome: a Turkish referred sample. Autism. 2014 Feb;18(2):178–84. doi: 10.1177/1362361312457716. X-122987894
2810 Tao VQ, Chan KY, Chu YW, . The clinical impact of chromosomal microarray on paediatric care in Hong Kong. PLoS One. 2014;9(10):e109629. doi: 10.1371/journal.pone.0109629. X-125333781
2811 Tavassoli T, Hoekstra RA, Baron-Cohen S. The Sensory Perception Quotient (SPQ): development and validation of a new sensory questionnaire for adults with and without autism. Mol Autism. 2014;5:29. doi: 10.1186/2040-2392-5-29. X-124791196
2812 Taylor JL, Mailick MR. A longitudinal examination of 10-year change in vocational and educational activities for adults with autism spectrum disorders. Dev Psychol. 2014 Mar;50(3):699–708. doi: 10.1037/a0034297. X-124001150
2813 Taylor JL, Smith LE, Mailick MR. Engagement in vocational activities promotes behavioral development for adults with autism spectrum disorders. J Autism Dev Disord. 2014 Jun;44(6):1447–60. doi: 10.1007/s10803-013-2010-9. X-124287880
2814 Tellegen CL, Sanders MR. A randomized controlled trial evaluating a brief parenting program with children with autism spectrum disorders. J Consult Clin Psychol. 2014 Dec;82(6):1193–200. doi: 10.1037/a0037246. X-124979315
2815 Tetef S. Effectiveness of Transmucosal Sedation for Special Needs Populations in the Ambulatory Care Setting. AORN Journal. 2014;100(6):651–69 19p. doi: 10.1016/j.aorn.2014.04.019. Language: English. Entry Date: 20141206. Revision Date: 20150818. Publication Type: Journal Article. X-1, X-225453684
2816 Thomas KC, Parish SL, Williams CS. Healthcare expenditures for autism during times of school transition: some vulnerable families fall behind. Matern Child Health J. 2014 Oct;18(8):1936–44. doi: 10.1007/s10995-014-1439-6. X-124553795
2817 Thompson DG, Tielsch-Goddard A. Improving management of patients with autism spectrum disorder having scheduled surgery: optimizing practice. J Pediatr Health Care. 2014 Sep–Oct;28(5):394–403. doi: 10.1016/j.pedhc.2013.09.007. X-124287372
2818 Thompson N, Yoshinaga-Itano C. Enhancing the development of infants and toddlers with dual diagnosis of autism spectrum disorder and deafness. Semin Speech Lang. 2014 Nov;35(4):321–30. doi: 10.1055/s-0034-1389104. X-125321856
2819 Thrasher A. Video modeling for children with dual diagnosis of deafness or hard of hearing and autism spectrum disorder to promote peer interaction. Semin Speech Lang. 2014 Nov;35(4):331–42. doi: 10.1055/s-0034-1389105. X-1, X-2, X-3, X-425321857
2820 Timimi S. Children’s behaviour problems: a NICE mess. Int J Clin Pract. 2014 Sep;68(9):1053–5. doi: 10.1111/ijcp.12442. X-125196181
2821 Titeca D, Roeyers H, Josephy H, . Preschool predictors of mathematics in first grade children with autism spectrum disorder. Res Dev Disabil. 2014 Nov;35(11):2714–27. doi: 10.1016/j.ridd.2014.07.012. X-125068926
2822 Tomlinson M, Yasamy MT, Emerson E, . Setting global research priorities for developmental disabilities, including intellectual disabilities and autism. J Intellect Disabil Res. 2014 Dec;58(12):1121–30. doi: 10.1111/jir.12106. X-124397279
2823 Tonge B, Brereton A, Kiomall M, . A randomised group comparison controlled trial of ‘preschoolers with autism’: a parent education and skills training intervention for young children with autistic disorder. Autism. 2014 Feb;18(2):166–77. doi: 10.1177/1362361312458186. X-122987897
2824 Tonge BJ, Bull K, Brereton A, . A review of evidence-based early intervention for behavioural problems in children with autism spectrum disorder: the core components of effective programs, child-focused interventions and comprehensive treatment models. Current Opinion in Psychiatry. 2014;27(2):158–65 8p. doi: 10.1097/YCO.0000000000000043. Language: English. Entry Date: 20141010. Revision Date: 20150819. Publication Type: Journal Article. X-224452070
2825 Towle PO, Vacanti-Shova K, Shah S, . School-aged functioning of children diagnosed with autism spectrum disorder before age three: parent-reported diagnostic, adaptive, medication, and school placement outcomes. J Autism Dev Disord. 2014 Jun;44(6):1357–72. doi: 10.1007/s10803-013-1997-2. X-124346492
2826 Trembath D, Iacono T, Lyon K, . Augmentative and alternative communication supports for adults with autism spectrum disorders. Autism. 2014 Nov;18(8):891–902. doi: 10.1177/1362361313486204. X-124104514
2827 Trent S, Fry JP, Ojarikre OA, . Altered brain gene expression but not steroid biochemistry in a genetic mouse model of neurodevelopmental disorder. Mol Autism. 2014;5(1):21. doi: 10.1186/2040-2392-5-21. X-124602487
2828 Trezise KL, Gray KM, Taffe J, . Working memory in adolescent males with Down syndrome and males with autism and intellectual disability: Implications for the classroom. Journal of Intellectual & Developmental Disability. 2014;39(1):24–34 11p. doi: 10.3109/13668250.2013.874550. Language: English. Entry Date: 20140311. Revision Date: 20150824. Publication Type: Journal Article. X-1
2829 Troyb E, Orinstein A, Tyson K, . Restricted and repetitive behaviors in individuals with a history of ASDs who have achieved optimal outcomes. J Autism Dev Disord. 2014 Dec;44(12):3168–84. doi: 10.1007/s10803-014-2182-y. X-125030967
2830 Troyb E, Orinstein A, Tyson K, . Academic abilities in children and adolescents with a history of autism spectrum disorders who have achieved optimal outcomes. Autism. 2014 Apr;18(3):233–43. doi: 10.1177/1362361312473519. X-124096312
2831 Troyb E, Rosenthal M, Eigsti IM, . Executive functioning in individuals with a history of ASDs who have achieved optimal outcomes. Child Neuropsychol. 2014;20(4):378–97. doi: 10.1080/09297049.2013.799644. X-123731181
2832 Tsai WH, Hwang YS, Hung TY, . Association between mechanical ventilation and neurodevelopmental disorders in a nationwide cohort of extremely low birth weight infants. Res Dev Disabil. 2014 Jul;35(7):1544–50. doi: 10.1016/j.ridd.2014.03.048. X-124769371
2833 Tseng A, Bansal R, Liu J, . Using the Circumplex Model of Affect to Study Valence and Arousal Ratings of Emotional Faces by Children and Adults with Autism Spectrum Disorders. Journal of Autism & Developmental Disorders. 2014;44(6):1332–46 15p. doi: 10.1007/s10803-013-1993-6. Language: English. Entry Date: 20140520. Revision Date: 20150710. Publication Type: Journal Article. X-124234677
2834 Tsilioni I, Dodman N, Petra AI, . Elevated serum neurotensin and CRH levels in children with autistic spectrum disorders and tail-chasing Bull Terriers with a phenotype similar to autism. Transl Psychiatry. 2014;4:e466. doi: 10.1038/tp.2014.106. X-125313509
2835 Tsui GH, Rutherford MD. Video self-modeling is an effective intervention for an adult with autism. Case Rep Neurol Med. 2014;2014:425897. doi: 10.1155/2014/425897. X-125276447
2836 Tsunemi K, Tamura A, Ogawa S, . Intensive exposure to narrative in story books as a possibly effective treatment of social perspective-taking in schoolchildren with autism. Front Psychol. 2014;5:2. doi: 10.3389/fpsyg.2014.00002. X-1, X-324474946
2837 Turygin N, Matson JL, Adams H. Prevalence of co-occurring disorders in a sample of adults with mild and moderate intellectual disabilities who reside in a residential treatment setting. Res Dev Disabil. 2014 Jul;35(7):1802–8. doi: 10.1016/j.ridd.2014.01.027. X-124656808
2838 Tye C, Battaglia M, Bertoletti E, . Altered neurophysiological responses to emotional faces discriminate children with ASD, ADHD and ASD+ADHD. Biol Psychol. 2014 Dec;103:125–34. doi: 10.1016/j.biopsycho.2014.08.013. X-125179537
2839 Tyler K, MacDonald M, Menear K. Physical activity and physical fitness of school-aged children and youth with autism spectrum disorders. Autism Res Treat. 2014;2014:312163. doi: 10.1155/2014/312163. X-125309753
2840 Udensi UK, Tchounwou PB. Dual effect of oxidative stress on leukemia cancer induction and treatment. J Exp Clin Cancer Res. 2014;33:106. doi: 10.1186/s13046-014-0106-5. X-125519934
2841 Ugur C, Saday Duman N, Bektas O, . Antiepileptic treatment in a child with Landau Kleffner syndrome: a case report. Turk Psikiyatri Derg. 2014 Winter;25(4):282–6. X-125487625
2842 Uljarevic M, Prior MR, Leekam SR. First evidence of sensory atypicality in mothers of children with Autism Spectrum Disorder (ASD). Mol Autism. 2014;5(1):26. doi: 10.1186/2040-2392-5-26. X-124694290
2843 Ung D, Arnold EB, De Nadai AS, . Inter-rater Reliability of the Anxiety Disorders Interview Schedule for DSM-IV in High-Functioning Youth with Autism Spectrum Disorder. J Dev Phys Disabil. 2014 Feb 1;26(1):53–65. doi: 10.1007/s10882-013-9343-3. X-124683302
2844 Urbano M, Okwara L, Manser P, . A trial of D-cycloserine to treat stereotypies in older adolescents and young adults with autism spectrum disorder. Clin Neuropharmacol. 2014 May–Jun;37(3):69–72. doi: 10.1097/wnf.0000000000000033. X-124824660
2845 Uutela M, Lindholm J, Rantamaki T, . Distinctive behavioral and cellular responses to fluoxetine in the mouse model for Fragile X syndrome. Front Cell Neurosci. 2014;8:150. doi: 10.3389/fncel.2014.00150. X-124904293
2846 Valenti M, La Malfa G, Tomassini A, . Burnout among therapists working with persons with autism after the 2009 earthquake in L’Aquila, Italy: a longitudinal comparative study. J Psychiatr Ment Health Nurs. 2014 Apr;21(3):234–40. doi: 10.1111/jpm.12054. X-123552108
2847 Valicenti-McDermott M, Burrows B, Bernstein L, . Use of complementary and alternative medicine in children with autism and other developmental disabilities: associations with ethnicity, child comorbid symptoms, and parental stress. J Child Neurol. 2014 Mar;29(3):360–7. doi: 10.1177/0883073812474489. X-1, X-323372032
2848 Vallortigara J, Rangarajan S, Whitfield D, . Dynamin1 concentration in the prefrontal cortex is associated with cognitive impairment in Lewy body dementia. F1000Res. 2014;3:108. doi: 10.12688/f1000research.3786.1. X-125671083
2849 van de Lagemaat LN, Nijhof B, Bosch DG, . Age-related decreased inhibitory vs. excitatory gene expression in the adult autistic brain. Front Neurosci. 2014;8:394. doi: 10.3389/fnins.2014.00394. X-125538548
2850 van den Bergh SF, Scheeren AM, Begeer S, . Age related differences of executive functioning problems in everyday life of children and adolescents in the autism spectrum. J Autism Dev Disord. 2014 Aug;44(8):1959–71. doi: 10.1007/s10803-014-2071-4. X-124562693
2851 van Rijn S, Stockmann L, van Buggenhout G, . Social cognition and underlying cognitive mechanisms in children with an extra X chromosome: a comparison with autism spectrum disorder. Genes Brain Behav. 2014 Jun;13(5):459–67. doi: 10.1111/gbb.12134. X-124655419
2852 Vanderwerker L, Akincigil A, Olfson M, . Foster care, externalizing disorders, and antipsychotic use among Medicaid-enrolled youths. Psychiatr Serv. 2014 Oct;65(10):1281–4. doi: 10.1176/appi.ps.201300455. X-125124057
2853 Vara AS, Pang EW, Doyle-Thomas KA, . Is inhibitory control a ‘no-go’ in adolescents with autism spectrum disorder? Mol Autism. 2014;5(1):6. doi: 10.1186/2040-2392-5-6. X-124485230
2854 Varella AA, de Souza DG. Emergence of auditory-visual relations from a visual-visual baseline with auditory-specific consequences in individuals with autism. J Exp Anal Behav. 2014 Jul;102(1):139–49. doi: 10.1002/jeab.93. X-1, X-3, X-424965883
2855 Ventola P, Friedman HE, Anderson LC, . Improvements in social and adaptive functioning following short-duration PRT program: a clinical replication. J Autism Dev Disord. 2014 Nov;44(11):2862–70. doi: 10.1007/s10803-014-2145-3. X-3, X-424915928
2856 Ventola P, Saulnier C, Steinberg E, . Early-Emerging Social Adaptive Skills in Toddlers with Autism Spectrum Disorders: An Item Analysis. Journal of Autism & Developmental Disorders. 2014;44(2):283–93 11p. doi: 10.1007/s10803-011-1278-x. Language: English. Entry Date: 20140129. Revision Date: 20150710. Publication Type: Journal Article. X-121567256
2857 Verly M, Verhoeven J, Zink I, . Altered functional connectivity of the language network in ASD: Role of classical language areas and cerebellum. Neuroimage Clin. 2014;4:374–82. doi: 10.1016/j.nicl.2014.01.008. X-124567909
2858 Vernon TW. Fostering a social child with autism: a moment-by-moment sequential analysis of an early social engagement intervention. J Autism Dev Disord. 2014 Dec;44(12):3072–82. doi: 10.1007/s10803-014-2173-z. X-3, X-424974256
2859 Vivanti G, Paynter J, Duncan E, . Effectiveness and feasibility of the early start denver model implemented in a group-based community childcare setting. J Autism Dev Disord. 2014 Dec;44(12):3140–53. doi: 10.1007/s10803-014-2168-9. X-124974255
2860 Vogan VM, Morgan BR, Lee W, . The neural correlates of visuo-spatial working memory in children with autism spectrum disorder: effects of cognitive load. J Neurodev Disord. 2014;6(1):19. doi: 10.1186/1866-1955-6-19. X-125057329
2861 Vogindroukas I, Chelas EN, Petridis NE. Reading the Mind in the Eyes Test (Children’s Version): a comparison study between children with typical development, children with high-functioning autism and typically developed adults. Folia Phoniatr Logop. 2014;66(1–2):18–24. doi: 10.1159/000363697. X-125472789
2862 Vohra R, Madhavan S, Khanna R, . Child’s autism severity: effect on West Virginia caregiver satisfaction with school services. W V Med J. 2014 Sep–Oct;110(5):32–9. X-1
2863 Vohra R, Madhavan S, Sambamoorthi U, . Access to services, quality of care, and family impact for children with autism, other developmental disabilities, and other mental health conditions. Autism. 2014 Oct;18(7):815–26. doi: 10.1177/1362361313512902. X-124353274
2864 Voigt RG, Mellon MW, Katusic SK, . Dietary docosahexaenoic acid supplementation in children with autism. J Pediatr Gastroenterol Nutr. 2014 Jun;58(6):715–22. doi: 10.1097/mpg.0000000000000260.24345834
2865 Wachtel LE, Reti IM, Ying H. Stability of intraocular pressure after retinal reattachment surgery during electroconvulsive therapy for intractable self-injury in a 12-year-old autistic boy. J ect. 2014 Mar;30(1):73–6. doi: 10.1097/YCT.0b013e31829b2d61. X-1, X-3, X-423812023
2866 Wagner DV, Borduin CM, Kanne SM, . Multisystemic therapy for disruptive behavior problems in youths with autism spectrum disorders: a progress report. J Marital Fam Ther. 2014 Jul;40(3):319–31. doi: 10.1111/jmft.12012. X-2, X-324749815
2867 Waite A. On an Even Keel. OT Practice. 2014;19(18):7–10 4p. Language: English. Entry Date: 20141017. Revision Date: 20150820. Publication Type: Journal Article. X-1, X-2
2868 Wallace MT, Stevenson RA. The construct of the multisensory temporal binding window and its dysregulation in developmental disabilities. Neuropsychologia. 2014 2015-07-15;64:105–23. doi: http://dx.doi.org/10.1016/j.neuropsychologia.2014.08.005; 2014-48956-013. X-125128432
2869 Wang HY, Berg C. Participation of young adults with high-functioning autism in Taiwan: a pilot study. OTJR (Thorofare N J). 2014 Winter;34(1):41–51. X-124669398
2870 Ward CS. Autism’s cancer connection: the anti-proliferation hypothesis and why it may matter. Med Hypotheses. 2014 Jan;82(1):26–35. doi: 10.1016/j.mehy.2013.10.029. X-124275522
2871 Warfield ME, Chiri G, Leutz WN, . Family well-being in a participant-directed autism waiver program: the role of relational coordination. J Intellect Disabil Res. 2014 Dec;58(12):1091–104. doi: 10.1111/jir.12102. X-125330124
2872 Waris P, Lindberg N, Kettunen K, . Catatonic features in adolescents with schizophrenia with and without a comorbid pervasive developmental disorder. Child Adolesc Psychiatry Ment Health. 2014;8:16. doi: 10.1186/1753-2000-8-16. X-124914405
2873 Warlaumont AS, Richards JA, Gilkerson J, . A social feedback loop for speech development and its reduction in autism. Psychol Sci. 2014 Jul;25(7):1314–24. doi: 10.1177/0956797614531023. X-124840717
2874 Warren Z, Zheng Z, Das S, . Brief Report: Development of a Robotic Intervention Platform for Young Children with ASD. J Autism Dev Disord. 2014 Dec 14 doi: 10.1007/s10803-014-2334-0. X-3, X-4
2875 Warreyn P, Roeyers H. See what I see, do as I do: promoting joint attention and imitation in preschoolers with autism spectrum disorder. Autism. 2014 Aug;18(6):658–71. doi: 10.1177/1362361313493834. X-124104513
2876 Watanabe T, Abe O, Kuwabara H, . Mitigation of sociocommunicational deficits of autism through oxytocin-induced recovery of medial prefrontal activity: a randomized trial. JAMA Psychiatry. 2014 Feb;71(2):166–75. doi: 10.1001/jamapsychiatry.2013.3181. X-124352377
2877 Watkins N, Rapp JT. Environmental enrichment and response cost: immediate and subsequent effects on stereotypy. J Appl Behav Anal. 2014 Spring;47(1):186–91. doi: 10.1002/jaba.97. X-3, X-424424774
2878 Watkins N, Sparling E. The Effectiveness of the Snug Vest on Stereotypic Behaviors in Children Diagnosed With an Autism Spectrum Disorder. Behav Modif. 2014 May;38(3):412–27. doi: 10.1177/0145445514532128. X-3, X-424778434
2879 Weeks S, Grimmer K, Boshoff K, . Conducting robust intervention trials to address the sensory needs of children with autism spectrum disorder: design challenges in an Australian context. British Journal of Occupational Therapy (College of Occupational Therapists Limited). 2014;77(10):533–5 3p. doi: 10.4276/030802214X14122630932557. Language: English. Entry Date: 20141022. Revision Date: 20151015. Publication Type: Journal Article. Journal Subset: Allied Health. X-1
2880 Wehman PH, Schall CM, McDonough J, . Competitive employment for youth with autism spectrum disorders: early results from a randomized clinical trial. J Autism Dev Disord. 2014 Mar;44(3):487–500. doi: 10.1007/s10803-013-1892-x. X-123893098
2881 Wei X, Wagner M, Christiano ER, . Special Education Services Received by Students with Autism Spectrum Disorders from Preschool through High School. J Spec Educ. 2014 Nov;48(3):167–79. doi: 10.1177/0022466913483576. X-125419002
2882 Weiner RH, Greene RL. Intention-based therapy for autism spectrum disorder: promising results of a wait-list control study in children. Explore (NY). 2014 Jan–Feb;10(1):13–23. doi: 10.1016/j.explore.2013.10.005. X-424439092
2883 Weiss AL, Rohland P. “Measuring up” to ethical standards in service delivery to college students on the Autism Spectrum: A practical application of Powell’s model for ethical practices in clinical phonetics and linguistics. Clin Linguist Phon. 2014 Jul–Aug;28(7–8):627–38. doi: 10.3109/02699206.2014.927002. X-125000383
2884 Weiss JA. Transdiagnostic Case Conceptualization of Emotional Problems in Youth with ASD: An Emotion Regulation Approach. Clin Psychol (New York). 2014 Dec;21(4):331–50. doi: 10.1111/cpsp.12084. X-125673923
2885 Wesseling H, Guest PC, Lee CM, . Integrative proteomic analysis of the NMDA NR1 knockdown mouse model reveals effects on central and peripheral pathways associated with schizophrenia and autism spectrum disorders. Mol Autism. 2014;5:38. doi: 10.1186/2040-2392-5-38. X-125061506
2886 West PR, Amaral DG, Bais P, . Metabolomics as a tool for discovery of biomarkers of autism spectrum disorder in the blood plasma of children. PLoS One. 2014;9(11):e112445. doi: 10.1371/journal.pone.0112445. X-125380056
2887 Westby CE. Social neuroscience and theory of mind. Folia Phoniatr Logop. 2014;66(1–2):7–17. doi: 10.1159/000362877. X-125472788
2888 Wetherby AM, Guthrie W, Woods J, . Parent-implemented social intervention for toddlers with autism: an RCT. Pediatrics. 2014 Dec;134(6):1084–93. doi: 10.1542/peds.2014-0757. X-125367544
2889 White E. Science, pseudoscience, and the frontline practitioner: the vaccination/autism debate. J Evid Based Soc Work. 2014;11(3):269–74. doi: 10.1080/15433714.2012.759470. X-124857555
2890 White SW, Smith LA, Schry AR. Assessment of global functioning in adolescents with autism spectrum disorders: utility of the Developmental Disability-Child Global Assessment Scale. Autism. 2014 May;18(4):362–9. doi: 10.1177/1362361313481287. X-123965288
2891 Whitfield DR, Vallortigara J, Alghamdi A, . Assessment of ZnT3 and PSD95 protein levels in Lewy body dementias and Alzheimer’s disease: association with cognitive impairment. Neurobiol Aging. 2014 Dec;35(12):2836–44. doi: 10.1016/j.neurobiolaging.2014.06.015. X-125104558
2892 Winburn E, Charlton J, McConachie H, . Parents’ and child health professionals’ attitudes towards dietary interventions for children with autism spectrum disorders. J Autism Dev Disord. 2014 Apr;44(4):747–57. doi: 10.1007/s10803-013-1922-8. X-123996225
2893 Wink LK, Early M, Schaefer T, . Body mass index change in autism spectrum disorders: comparison of treatment with risperidone and aripiprazole. J Child Adolesc Psychopharmacol. 2014 Mar;24(2):78–82. doi: 10.1089/cap.2013.0099.24564519
2894 Wolff ER, Madlon-Kay DJ. Childhood vaccine beliefs reported by Somali and non-Somali parents. J Am Board Fam Med. 2014 Jul–Aug;27(4):458–64. doi: 10.3122/jabfm.2014.04.130275. X-125002000
2895 Wong AY, Hsia Y, Chan EW, . The variation of psychopharmacological prescription rates for people with autism spectrum disorder (ASD) in 30 countries. Autism Res. 2014 Oct;7(5):543–54. doi: 10.1002/aur.1391. X-124895332
2896 Wong JD, Mailick MR, Greenberg JS, . Daily Work Stress and Awakening Cortisol in Mothers of Individuals with Autism Spectrum Disorders or Fragile X Syndrome. Fam Relat. 2014 Feb;63(1):135–47. doi: 10.1111/fare.12055. X-125313265
2897 Wood A. Prenatal exposure to sodium valproate is associated with increased risk of childhood autism and autistic spectrum disorder. Evidence Based Nursing. 2014;17(3):84- 1p. doi: 10.1136/eb-2013-101422. Language: English. Entry Date: 20140627. Revision Date: 20150820. Publication Type: Journal Article. X-123999195
2898 Wood JJ, Fujii C, Renno P, . Impact of cognitive behavioral therapy on observed autism symptom severity during school recess: a preliminary randomized, controlled trial. J Autism Dev Disord. 2014 Sep;44(9):2264–76. doi: 10.1007/s10803-014-2097-7. X-424671750
2899 Worley MJ, Tate SR, Granholm E, . Mediated and moderated effects of neurocognitive impairment on outcomes of treatment for substance dependence and major depression. J Consult Clin Psychol. 2014 Jun;82(3):418–28. doi: 10.1037/a0036033. X-124588403
2900 Worley MJ, Trim RS, Tate SR, . Self-efficacy and social networks after treatment for alcohol or drug dependence and major depression: disentangling person and time-level effects. Psychol Addict Behav. 2014 Dec;28(4):1220–9. doi: 10.1037/a0037901. X-125347018
2901 Wright B, Marshall D, Collingridge Moore D, . Autism Spectrum Social Stories In Schools Trial (ASSSIST): study protocol for a feasibility randomised controlled trial analysing clinical and cost-effectiveness of Social Stories in mainstream schools. BMJ Open. 2014;4(7):e005952. doi: 10.1136/bmjopen-2014-005952. X-1
2902 Wu CM, Kung PT, Li CI, . The difference in medical utilization and associated factors between children and adolescents with and without autism spectrum disorders. Res Dev Disabil. 2014 Oct 18;36c:78–86. doi: 10.1016/j.ridd.2014.09.019. X-125462468
2903 Wu X, Bai Y, Tan T, . Lithium ameliorates autistic-like behaviors induced by neonatal isolation in rats. Front Behav Neurosci. 2014;8:234. doi: 10.3389/fnbeh.2014.00234. X-125018711
2904 Xin JF, Leonard DA. Using iPads to Teach Communication Skills of Students with Autism. J Autism Dev Disord. 2014 Oct 8 doi: 10.1007/s10803-014-2266-8. X-3, X-4
2905 Xiong XX, He M, Chen XQ. [Progress in autism: de novo mutation and CHD8 functions]. Sheng Li Ke Xue Jin Zhan. 2014 Jun;45(3):185–9. X-125219269
2906 Xu D, Richards JA, Gilkerson J. Automated analysis of child phonetic production using naturalistic recordings. J Speech Lang Hear Res. 2014 Oct;57(5):1638–50. doi: 10.1044/2014_jslhr-s-13-0037. X-124824489
2907 Yamkovenko S, Waite A. Industry News. OT Practice. 2014;19(1):2- 1p. Language: English. Entry Date: 20140122. Revision Date: 20150712. Publication Type: Journal Article. Journal Subset: Allied Health. X-1
2908 Yang HC, Lee IC, Lee IC. Visual feedback and target size effects on reach-to-grasp tasks in children with autism. J Autism Dev Disord. 2014 Dec;44(12):3129–39. doi: 10.1007/s10803-014-2165-z. X-1, X-324974254
2909 Yang P, Chang CL. Glutamate-mediated signaling and autism spectrum disorders: emerging treatment targets. Curr Pharm Des. 2014;20(32):5186–93. X-124410563
2910 Yashoda R, Puranik MP. Oral health status and parental perception of child oral health related quality-of-life of children with autism in Bangalore, India. J Indian Soc Pedod Prev Dent. 2014 Apr–Jun;32(2):135–9. doi: 10.4103/0970-4388.130967. X-124739913
2911 Yassa HA. Autism: a form of lead and mercury toxicity. Environ Toxicol Pharmacol. 2014 Nov;38(3):1016–24. doi: 10.1016/j.etap.2014.10.005. X-1, X-325461563
2912 Yasuda Y, Hashimoto R, Ohi K, . Cognitive inflexibility in Japanese adolescents and adults with autism spectrum disorders. World J Psychiatry. 2014 Jun 22;4(2):42–8. doi: 10.5498/wjp.v4.i2.42. X-125019056
2913 Yoo HJ, Bahn G, Cho IH, . A randomized controlled trial of the Korean version of the PEERS((R)) parent-assisted social skills training program for teens with ASD. Autism Res. 2014 Feb;7(1):145–61. doi: 10.1002/aur.1354. X-124408892
2914 Youngster I, Zachor DA, Gabis LV, . CYP2D6 genotyping in paediatric patients with autism treated with risperidone: a preliminary cohort study. Dev Med Child Neurol. 2014 Oct;56(10):990–4. doi: 10.1111/dmcn.12470. X-1, X-324828442
2915 Yu Q, Peng Y, Mishra V, . Microstructure, length, and connection of limbic tracts in normal human brain development. Front Aging Neurosci. 2014;6:228. doi: 10.3389/fnagi.2014.00228. X-125221509
2916 Yucel GH, Belger A, Bizzell J, . Abnormal Neural Activation to Faces in the Parents of Children with Autism. Cereb Cortex. 2014 Jul 23 doi: 10.1093/cercor/bhu147. X-1
2917 Zablotsky B, Kalb LG, Freedman B, . Health care experiences and perceived financial impact among families of children with an autism spectrum disorder. Psychiatr Serv. 2014 Mar 1;65(3):395–8. doi: 10.1176/appi.ps.201200552. X-124584528
2918 Zachor DA, Ben-Itzchak E. The relationship between clinical presentation and unusual sensory interests in autism spectrum disorders: A preliminary investigation. Journal of Autism and Developmental Disorders. 2014 2015-02-24;44(1):229–35. doi: http://dx.doi.org/10.1007/s10803-013-1867-y; 2013-23011-001. X-1
2919 Zamora I, Harley EK, Green SA, . How sex of children with autism spectrum disorders and access to treatment services relates to parental stress. Autism Res Treat. 2014;2014:721418. doi: 10.1155/2014/721418. X-125580295
2920 Zamzow RM, Christ SE, Saklayen SS, . Effect of propranolol on facial scanning in autism spectrum disorder: a preliminary investigation. J Clin Exp Neuropsychol. 2014;36(4):431–45. doi: 10.1080/13803395.2014.904844. X-3, X-424730708
2921 Zeidan-Chulia F, de Oliveira BH, Salmina AB, . Altered expression of Alzheimer’s disease-related genes in the cerebellum of autistic patients: a model for disrupted brain connectome and therapy. Cell Death Dis. 2014;5:e1250. doi: 10.1038/cddis.2014.227. X-124853428
2922 Zhang W, Yan TT, Du YS, . Brief report: effects of solution-focused brief therapy group-work on promoting post-traumatic growth of mothers who have a child with ASD. J Autism Dev Disord. 2014 Aug;44(8):2052–6. doi: 10.1007/s10803-014-2051-8. X-124488119
2923 Zhao ZQ, Jia SW, Hu S, . Evaluating the effectiveness of electro-acupuncture as a treatment for childhood autism using single photon emission computed tomography. Chin J Integr Med. 2014 Jan;20(1):19–23. doi: 10.1007/s11655-014-1680-2. X-324374754
2924 Zhou WZ, Ye AY, Sun ZK, . Statistical analysis of twenty years (1993 to 2012) of data from mainland China’s first intervention center for children with autism spectrum disorder. Mol Autism. 2014;5:52. doi: 10.1186/2040-2392-5-52. X-125694804
2925 Zhou Y-y, Huang C-j, Liu J, . Efficacy of medication combined with sensory integration therapy for children with comorbid high-functioning autism spectrum disorder and attention deficit and hyperactivity disorder. Chinese Journal of Clinical Psychology. 2014 2015-12-09;22(6):1137–40; 2015-13180-041. X-5
2926 Zhu H, Fan Y, Guo H, . Reduced interhemispheric functional connectivity of children with autism spectrum disorder: evidence from functional near infrared spectroscopy studies. Biomed Opt Express. 2014 Apr 1;5(4):1262–74. doi: 10.1364/boe.5.001262. X-124761305
2927 Ziv Y, Hadad B, Khateeb Y. Social Information Processing in Preschool Children Diagnosed with Autism Spectrum Disorder. Journal of Autism & Developmental Disorders. 2014;44(4):846–59 14p. doi: 10.1007/s10803-013-1935-3. Language: English. Entry Date: 20140311. Revision Date: 20150710. Publication Type: Journal Article. X-124005986
2928 Zuckerman KE, Lindly OJ, Bethell CD, . Family impacts among children with autism spectrum disorder: the role of health care quality. Acad Pediatr. 2014 Jul–Aug;14(4):398–407. doi: 10.1016/j.acap.2014.03.011. X-124976352
2929 Zuckerman KE, Sinche B, Mejia A, . Latino parents’ perspectives on barriers to autism diagnosis. Acad Pediatr. 2014 May–Jun;14(3):301–8. doi: 10.1016/j.acap.2013.12.004. X-124767783
2930 Circumcision and autism. Arch Dis Child. 2015 Apr;100(4):369. doi: 10.1136/archdischild-2015-308402. X-125715006
2931 Identification of neuromotor deficits common to autism spectrum disorder and attention deficit/hyperactivity disorder, and imitation deficits specific to autism spectrum disorder. European Child & Adolescent Psychiatry. 2015;24(12):1497–507 11p. doi: 10.1007/s00787-015-0753-x. Language: English. Entry Date: 20151124. Revision Date: 20151124. Publication Type: Article. Journal Subset: Biomedical. X-1, X-226233230
2932 Development of the Classroom Sensory Environment Assessment (CSEA). American Journal of Occupational Therapy. 2015;69(6):1–9 p. doi: 10.5014/ajot.2015.019430. Language: English. Entry Date: 20151109. Revision Date: 20151112. Publication Type: Article. Journal Subset: Allied Health. X-1, X-2, X-3
2933 State of the Science: A Roadmap for Research in Sensory Integration. American Journal of Occupational Therapy. 2015;69:(6)1–7 p. doi: 10.5014/ajot.2015.019539. Language: English. Entry Date: 20151109. Revision Date: 20151112. Publication Type: Article. Journal Subset: Allied Health. X-1, X-2
2934 Early Identification of Autism Spectrum Disorder: Recommendations for Practice and Research. Pediatrics. 2015;136:S10–S40 31p. doi: 10.1542/peds.2014-3667C. Language: English. Entry Date: 20151009. Revision Date: 20151015. Publication Type: Article. Supplement Title: 2015 Supplement. Journal Subset: Biomedical. X-1, X-226430168
2935 Failure in Pantomime Action Execution Correlates with the Severity of Social Behavior Deficits in Children with Autism: A Praxis Study. Journal of Autism & Developmental Disorders. 2015;45(10):3085–97 13p. doi: 10.1007/s10803-015-2461-2. Language: English. Entry Date: 20150925. Revision Date: 20151021. Publication Type: Article. Journal Subset: Biomedical. X-1, X-225962471
2936 Stimulus Over-Selectivity and Extinction-Induced Recovery of Performance as a Product of Intellectual Impairment and Autism Severity. Journal of Autism & Developmental Disorders. 2015;45(10):3098–106 9p. doi: 10.1007/s10803-015-2466-x. Language: English. Entry Date: 20150925. Revision Date: 20151021. Publication Type: Article. Journal Subset: Biomedical. X-1, X-225997597
2937 Patterns of Sensory Integration Dysfunction in Specific Populations: Evidence-Based Identification. Bethesda, Maryland: American Occupational Therapy Association; 2015. p. CE-1–CE-8 p.
2938 Effectiveness of Ayres Sensory Integration® and Sensory-Based Interventions for People With Autism Spectrum Disorder: A Systematic Review. American Journal of Occupational Therapy. 2015;69:(5)p1–p12 20p. doi: 10.5014/ajot.2015.018051. Language: English. Entry Date: 20151012. Revision Date: 20151012. Publication Type: Article. X-1, X-2
2939 Retrospective Analysis of Motor Development in Infants at High and Low Risk for Autism Spectrum Disorder. American Journal of Occupational Therapy. 2015;69(5):p1–p9 p. doi: 10.5014/ajot.2015.017525. Language: English. Entry Date: 20151012. Revision Date: 20151012. Publication Type: Article. X-1
2940 Brainstem White Matter Predicts Individual Differences in Manual Motor Difficulties and Symptom Severity in Autism. Journal of Autism & Developmental Disorders. 2015;45(9):3030–40 11p. doi: 10.1007/s10803-015-2467-9. Language: English. Entry Date: 20151016. Revision Date: 20151016. Publication Type: Article. X-1, X-226001365
2941 Untitled. Adapted Physical Activity Quarterly. 2015;32(3):279–82 4p. doi: 10.1123/APAQ.2015-0044. Language: English. Entry Date: 20150716. Revision Date: 20150923. Publication Type: Journal Article. X-527715175
2942 Mom Creates Weighted Vest From Husband’s Military Uniform. OT Practice. 2015;20(8):3- 1p. Language: English. Entry Date: 20150720. Revision Date: 20150923. Publication Type: Journal Article. X-1, X-2
2943 Keep your eye on. Brown University Child & Adolescent Behavior Letter. 2015;31(12):2– /3p. doi: 10.1002/cbl. Language: English. Entry Date: 20151119. Revision Date: 20151123. Publication Type: Article. Journal Subset: Biomedical. X-1, X-2
2944 Clinical Trial Investigates Drug for Autism. ASHA Leader. 2015;20(9):15- 1p. Language: English. Entry Date: 20150902. Revision Date: 20150923. Publication Type: Journal Article. X-1, X-2
2945 Reduction of Aggressive Episodes After Repeated Transdermal Nicotine Administration in a Hospitalized Adolescent with Autism Spectrum Disorder., <Blank>: Springer Science & Business Media B.V.; 2015. p. 3061–6 6p.
2946 LURASIDONE IMPROVES FUNCTION IN PATIENTS WITH AUTISM SPECTRUM DISORDER. Exceptional Parent. 2015;45:(6)14- 1p. Language: English. Entry Date: 20150818. Revision Date: 20150923. Publication Type: Journal Article. X-1, X-2
2947 LEGAL NEWS ROUND-UP. Occupational Health. 2015;67:(6)8- 1p. Language: English. Entry Date: 20150623. Revision Date: 20150923. Publication Type: Journal Article. X-1, X-2
2948 FDA approves first generic Abilify to treat mental illnesses. Mental Health Weekly. 2015;25(18):6–7 2p. doi: 10.1002/mhw.20472. Language: English. Entry Date: 20150518. Revision Date: 20151102. Publication Type: Journal Article. X-1, X-2
2949 Pharmacotherapy options in autism: Serious adverse effects, little efficacy. Brown University Child & Adolescent Psychopharmacology Update. 2015;17(3):1–3 p. doi: 10.1002/cpu.20228. Language: English. Entry Date: 20150302. Revision Date: 20150828. Publication Type: Journal Article. Journal Subset: Biomedical. X-1, X-2
2950 PEDIATRICS SUMMARY. Pediatrics. 2015;135(2):D1–6 1p. Language: English. Entry Date: 20150501. Revision Date: 20150710. Publication Type: Journal Article. X-1, X-2
2951 Abbott AE, Nair A, Keown CL, . Patterns of Atypical Functional Connectivity and Behavioral Links in Autism Differ Between Default, Salience, and Executive Networks. Cereb Cortex. 2015 Sep 7 doi: 10.1093/cercor/bhv191. X-1
2952 Abdeltawwab MM, Baz H. Automatic Pre-Attentive Auditory Responses: MMN to Tone Burst Frequency Changes in Autistic School-Age Children. J Int Adv Otol. 2015 Apr;11(1):36–41. doi: 10.5152/iao.2014.438. X-126223716
2953 Acab A, Muotri AR. The Use of Induced Pluripotent Stem Cell Technology to Advance Autism Research and Treatment. Neurotherapeutics. 2015 Jul;12(3):534–45. doi: 10.1007/s13311-015-0354-x. X-125851569
2954 Accardo PJ, Barrow W. Toe walking in autism: further observations. J Child Neurol. 2015 Apr;30(5):606–9. doi: 10.1177/0883073814521298. X-124563477
2955 Addis L, Ahn JW, Dobson R, . Microdeletions of ELP4 Are Associated with Language Impairment, Autism Spectrum Disorder, and Mental Retardation. Hum Mutat. 2015 Sep;36(9):842–50. doi: 10.1002/humu.22816. X-126010655
2956 Adelsky SJ. Review of Parenting on the autism spectrum: A survival guide. Journal of the American Academy of Child & Adolescent Psychiatry. 2015 2015-03-18;54(3):236–7. doi: http://dx.doi.org/10.1016/j.jaac.2015.01.004; 2015-08819-018. X-1, X-2
2957 Adibsereshki N, Nesayan A, Asadi Gandomani R, . The Effectiveness of Theory of Mind Training On the Social Skills of Children with High Functioning Autism Spectrum Disorders. Iran J Child Neurol. 2015 Summer;9(3):40–9. X-126401152
2958 Adler BA, Wink LK, Early M, . Drug-refractory aggression, self-injurious behavior, and severe tantrums in autism spectrum disorders: a chart review study. Autism. 2015 Jan;19(1):102–6. doi: 10.1177/1362361314524641. X-324571823
2959 Adler N, Dvash J, Shamay-Tsoory SG. Empathic Embarrassment Accuracy in Autism Spectrum Disorder. Autism Res. 2015 Jun;8(3):241–9. doi: 10.1002/aur.1439. X-125732043
2960 Adolfsson M, Simmeborn Fleischer A. Applying the ICF to identify requirements for students with Asperger syndrome in higher education. Dev Neurorehabil. 2015 Jun;18(3):190–202. doi: 10.3109/17518423.2013.819947. X-123957214
2961 Agarwal AK, Rai S, Upreti MC, . Day care as an innovative approach in psychiatry: Analysis of Lucknow experience. Indian J Psychiatry. 2015 Apr–Jun;57(2):162–4. doi: 10.4103/0019-5545.158157. X-126124522
2962 Aggarwal S, Angus B. Misdiagnosis versus missed diagnosis: diagnosing autism spectrum disorder in adolescents. Australas Psychiatry. 2015 Apr;23(2):120–3. doi: 10.1177/1039856214568214. X-125653302
2963 Ago Y, Condro MC, Tan YV, . Reductions in synaptic proteins and selective alteration of prepulse inhibition in male C57BL/6 mice after postnatal administration of a VIP receptor (VIPR2) agonist. Psychopharmacology (Berl). 2015 Jun;232(12):2181–9. doi: 10.1007/s00213-014-3848-z. X-125575489
2964 Aguilar-Valles A, Matta-Camacho E, Khoutorsky A, . Inhibition of Group I Metabotropic Glutamate Receptors Reverses Autistic-Like Phenotypes Caused by Deficiency of the Translation Repressor eIF4E Binding Protein 2. J Neurosci. 2015 Aug 5;35(31):11125–32. doi: 10.1523/jneurosci.4615-14.2015. X-126245973
2965 Ahouee SM, Shooshtari MH, Bidaki R. A girl with increased writing and painting activities associated with Turner’s syndrome and autistic spectrum disorder. Adv Biomed Res. 2015;4:91. doi: 10.4103/2277-9175.156655. X-126015917
2966 Aida T, Yoshida J, Nomura M, . Astroglial glutamate transporter deficiency increases synaptic excitability and leads to pathological repetitive behaviors in mice. Neuropsychopharmacology. 2015 Jun;40(7):1569–79. doi: 10.1038/npp.2015.26. X-125662838
2967 Akintunde ME, Rose M, Krakowiak P, . Increased production of IL-17 in children with autism spectrum disorders and co-morbid asthma. J Neuroimmunol. 2015 Sep 15;286:33–41. doi: 10.1016/j.jneuroim.2015.07.003. X-126298322
2968 Al Shirian S, Al Dera H. Descriptive characteristics of children with autism at Autism Treatment Center, KSA. Physiol Behav. 2015 Nov 1;151:604–8. doi: 10.1016/j.physbeh.2015.09.001. X-126343774
2969 Alaerts K, Geerlings F, Herremans L, . Functional Organization of the Action Observation Network in Autism: A Graph Theory Approach. PLoS One. 2015;10(8):e0137020. doi: 10.1371/journal.pone.0137020. X-126317222
2970 Al-Amin MM, Rahman MM, Khan FR, . Astaxanthin improves behavioral disorder and oxidative stress in prenatal valproic acid-induced mice model of autism. Behav Brain Res. 2015 Jun 1;286:112–21. doi: 10.1016/j.bbr.2015.02.041. X-125732953
2971 Alaniz ML, Galit E, Necesito CI, . Hand Strength, Handwriting, and Functional Skills in Children With Autism. Am J Occup Ther. 2015 Jul–Aug;69(4):6904220030p1–9. doi: 10.5014/ajot.2015.016022. X-1
2972 Aldaqre I, Paulus M, Sodian B. Referential gaze and word learning in adults with autism. Autism. 2015 Nov;19(8):944–55. doi: 10.1177/1362361314556784. X-125488004
2973 Aldinger KA, Lane CJ, Veenstra-VanderWeele J, . Patterns of Risk for Multiple Co-Occurring Medical Conditions Replicate Across Distinct Cohorts of Children with Autism Spectrum Disorder. Autism Res. 2015 May 24 doi: 10.1002/aur.1492. X-1
2974 Alexander M, Petri H, Ding Y, . Morbidity and medication in a large population of individuals with Down syndrome compared to the general population. Dev Med Child Neurol. 2015 Aug 18 doi: 10.1111/dmcn.12868. X-1
2975 Al-Heizan MO, AlAbdulwahab SS, Kachanathu SJ, . Sensory processing dysfunction among Saudi children with and without autism. J Phys Ther Sci. 2015 May;27(5):1313–6. doi: 10.1589/jpts.27.1313. X-126157208
2976 Allen KD, Vatland C, Bowen SL, . An evaluation of parent-produced video self-modeling to improve independence in an adolescent with intellectual developmental disorder and an autism spectrum disorder: a controlled case study. Behav Modif. 2015 Jul;39(4):542–56. doi: 10.1177/0145445515583247. X-125903581
2977 Allen ML, Hartley C, Cain K. Do iPads promote symbolic understanding and word learning in children with autism? Front Psychol. 2015;6:138. doi: 10.3389/fpsyg.2015.00138. X-1, X-325729376
2978 Alokam R, Singhal S, Srivathsav GS, . Design of dual inhibitors of ROCK-I and NOX2 as potential leads for the treatment of neuroinflammation associated with various neurological diseases including autism spectrum disorder. Mol Biosyst. 2015 Feb;11(2):607–17. doi: 10.1039/c4mb00570h. X-125465055
2979 Alquraini T, Mahoney G. An Exploratory Investigation of the Role of Parenting Stress in Relationship Focused Intervention. J Appl Res Intellect Disabil. 2015 Nov;28(6):536–47. doi: 10.1111/jar.12148. X-125727239
2980 Althaus M, Groen Y, Wijers AA, . Oxytocin enhances orienting to social information in a selective group of high-functioning male adults with autism spectrum disorder. Neuropsychologia. 2015 Oct 21 doi: 10.1016/j.neuropsychologia.2015.10.025. X-1
2981 Al-Zaid FS, Alhader AA, Al-Ayadhi LY. The second to fourth digit ratio (2D:4D) in Saudi boys with autism: A potential screening tool. Early Hum Dev. 2015 Jul;91(7):413–5. doi: 10.1016/j.earlhumdev.2015.04.007. X-125981494
2982 Aman M, Rettiganti M, Nagaraja HN, . Tolerability, Safety, and Benefits of Risperidone in Children and Adolescents with Autism: 21-Month Follow-up After 8-Week Placebo-Controlled Trial. J Child Adolesc Psychopharmacol. 2015 Aug;25(6):482–93. doi: 10.1089/cap.2015.0005.26262903
2983 Amaral CP, Simoes MA, Castelo-Branco MS. Neural signals evoked by stimuli of increasing social scene complexity are detectable at the single-trial level and right lateralized. PLoS One. 2015;10(3):e0121970. doi: 10.1371/journal.pone.0121970. X-125807525
2984 Amatachaya A, Jensen MP, Patjanasoontorn N, . The short-term effects of transcranial direct current stimulation on electroencephalography in children with autism: a randomized crossover controlled trial. Behav Neurol. 2015;2015:928631. doi: 10.1155/2015/928631.25861158
2985 Ament K, Mejia A, Buhlman R, . Evidence for Specificity of Motor Impairments in Catching and Balance in Children with Autism. Journal of Autism & Developmental Disorders. 2015;45(3):742–51 10p. doi: 10.1007/s10803-014-2229-0. Language: English. Entry Date: 20150226. Revision Date: 20150710. Publication Type: Journal Article. X-125231287
2986 Anagnostou E, Jones N, Huerta M, . Measuring social communication behaviors as a treatment endpoint in individuals with autism spectrum disorder. Autism. 2015 Jul;19(5):622–36. doi: 10.1177/1362361314542955. X-125096930
2987 Andell E, Tomson T, Carlsson S, . The incidence of unprovoked seizures and occurrence of neurodevelopmental comorbidities in children at the time of their first epileptic seizure and during the subsequent six months. Epilepsy Res. 2015 Jul;113:140–50. doi: 10.1016/j.eplepsyres.2015.04.002. X-125986201
2988 Ander BP, Barger N, Stamova B, . Atypical miRNA expression in temporal cortex associated with dysregulation of immune, cell cycle, and other pathways in autism spectrum disorders. Mol Autism. 2015;6:37. doi: 10.1186/s13229-015-0029-9. X-126146533
2989 Andersen PN, Skogli EW, Hovik KT, . Working memory arrest in children with high-functioning autism compared to children with attention-deficit/hyperactivity disorder: results from a 2-year longitudinal study. Autism. 2015 May;19(4):443–50. doi: 10.1177/1362361314524844. X-124604922
2990 Anderson D, Byrne-Barta D. Keeping the Child with Autism Spectrum Disorder Safe. AAACN Viewpoint. 2015;37(1):11–3 3p. Language: English. Entry Date: 20150213. Revision Date: 20150820. Publication Type: Journal Article. X-1, X-2
2991 Anderson GM, Montazeri F, de Bildt A. Network Approach to Autistic Traits: Group and Subgroup Analyses of ADOS Item Scores. J Autism Dev Disord. 2015 Oct;45(10):3115–32. doi: 10.1007/s10803-015-2537-z. X-1, X-226206232
2992 Andoh-Noda T, Akamatsu W, Miyake K, . Differentiation of multipotent neural stem cells derived from Rett syndrome patients is biased toward the astrocytic lineage. Mol Brain. 2015;8:31. doi: 10.1186/s13041-015-0121-2. X-126012557
2993 Angliker N, Burri M, Zaichuk M, . mTORC1 and mTORC2 have largely distinct functions in Purkinje cells. Eur J Neurosci. 2015 Oct;42(8):2595–612. doi: 10.1111/ejn.13051. X-126296489
2994 Angriman M, Caravale B, Novelli L, . Sleep in children with neurodevelopmental disabilities. Neuropediatrics. 2015 Jun;46(3):199–210. doi: 10.1055/s-0035-1550151. X-125918987
2995 Anketell PM, Saunders KJ, Gallagher SM, . Brief Report: Vision in Children with Autism Spectrum Disorder: What Should Clinicians Expect? J Autism Dev Disord. 2015 Sep;45(9):3041–7. doi: 10.1007/s10803-015-2431-8. X-125847754
2996 Antonucci N, Cirillo A, Siniscalco D. Beneficial Effects of Palmitoylethanolamide on Expressive Language, Cognition, and Behaviors in Autism: A Report of Two Cases. Case Rep Psychiatry. 2015;2015:325061. doi: 10.1155/2015/325061. X-3, X-426491593
2997 Aoki Y, Watanabe T, Abe O, . Oxytocin’s neurochemical effects in the medial prefrontal cortex underlie recovery of task-specific brain activity in autism: a randomized controlled trial. Mol Psychiatry. 2015 Apr;20(4):447–53. doi: 10.1038/mp.2014.74. X-125070538
2998 Arabameri E, Sotoodeh MS. Early developmental delay in children with autism: A study from a developing country. Infant Behav Dev. 2015 May;39:118–23. doi: 10.1016/j.infbeh.2015.02.017. X-125827390
2999 Aramaki E, Shikata S, Miyabe M, . Understanding the Relationship between Social Cognition and Word Difficulty. A Language Based Analysis of Individuals with Autism Spectrum Disorder. Methods Inf Med. 2015 Sep 22;54(5)doi: 10.3414/me15-01-0038. X-1
3000 Ardhanareeswaran K, Volkmar F. Introduction. Focus: autism spectrum disorders. Yale J Biol Med. 2015 Mar;88(1):3–4. X-1, X-225902571
3001 Aresti-Bartolome N, Garcia-Zapirain B. Cognitive rehabilitation system for children with autism spectrum disorder using serious games: A pilot study. Biomed Mater Eng. 2015 Aug 17;26(Suppl 1):S811–24. doi: 10.3233/bme-151373. X-1, X-326406079
3002 Arnold B, Elliott A, Laohamroonvorapongse D, . Autistic children and anesthesia: is their perioperative experience different? Paediatr Anaesth. 2015 Nov;25(11):1103–10. doi: 10.1111/pan.12739. X-126338278
3003 Arteaga G, Buritica E, Escobar MI, . Human prefrontal layer II interneurons in areas 46, 10 and 24. Colomb Med (Cali). 2015 Jan–Mar;46(1):19–25. X-126019381
3004 Ashwin C, Hietanen JK, Baron-Cohen S. Atypical integration of social cues for orienting to gaze direction in adults with autism. Mol Autism. 2015;6(1):5. doi: 10.1186/2040-2392-6-5. X-125685307
3005 Ashwood KL, Buitelaar J, Murphy D, . European clinical network: autism spectrum disorder assessments and patient characterisation. Eur Child Adolesc Psychiatry. 2015 Aug;24(8):985–95. doi: 10.1007/s00787-014-0648-2. X-125471824
3006 Ashwood KL, Tye C, Azadi B, . Brief Report: Adaptive Functioning in Children with ASD, ADHD and ASD + ADHD. J Autism Dev Disord. 2015 Jul;45(7):2235–42. doi: 10.1007/s10803-014-2352-y. X-125614019
3007 Atladottir HO, Schendel DE, Henriksen TB, . Gestational Age and Autism Spectrum Disorder: Trends in Risk Over Time. Autism Res. 2015 Sep 12 doi: 10.1002/aur.1525. X-1
3008 Atladottir HO, Schendel DE, Parner ET, . A Descriptive Study on the Neonatal Morbidity Profile of Autism Spectrum Disorders, Including a Comparison with Other Neurodevelopmental Disorders. J Autism Dev Disord. 2015 Aug;45(8):2429–42. doi: 10.1007/s10803-015-2408-7. X-125758820
3009 Auyeung B, Lombardo MV, Heinrichs M, . Oxytocin increases eye contact during a real-time, naturalistic social interaction in males with and without autism. Transl Psychiatry. 2015;5:e507. doi: 10.1038/tp.2014.146. X-125668435
3010 Au-Yeung SK, Kaakinen JK, Liversedge SP, . Processing of Written Irony in Autism Spectrum Disorder: An Eye-Movement Study. Autism Res. 2015 May 11 doi: 10.1002/aur.1490. X-1
3011 Auzou N, Dujardin K, Biundo R, . Diagnosing dementia in multiple system atrophy by applying Movement Disorder Society diagnostic criteria for Parkinson’s disease dementia. Parkinsonism Relat Disord. 2015 Oct;21(10):1273–7. doi: 10.1016/j.parkreldis.2015.08.013. X-126305998
3012 Avcil S, Baykara B, Baydur H, . [The validity and reliability of the Social Communication Questionnaire- Turkish form in autistics aged 4–18 years]. Turk Psikiyatri Derg. 2015 Spring;26(1):56–64. X-125742038
3013 Backer van Ommeren T, Koot HM, Scheeren AM, . Reliability and Validity of the Interactive Drawing Test: A Measure of Reciprocity for Children and Adolescents with Autism Spectrum Disorder. J Autism Dev Disord. 2015 Jul;45(7):1967–77. doi: 10.1007/s10803-014-2353-x. X-125630897
3014 Backstrom DC, Eriksson Domellof M, Linder J, . Cerebrospinal Fluid Patterns and the Risk of Future Dementia in Early, Incident Parkinson Disease. JAMA Neurol. 2015 Oct 1;72(10):1175–82. doi: 10.1001/jamaneurol.2015.1449. X-126258692
3015 Bacon C, Schneider M, Le Magueresse C, . Brain-specific Foxp1 deletion impairs neuronal development and causes autistic-like behaviour. Mol Psychiatry. 2015 May;20(5):632–9. doi: 10.1038/mp.2014.116. X-125266127
3016 Badgett N, Falcomata TS. A comparison of methodologies of brief functional analysis. Dev Neurorehabil. 2015;18(4):224–33. doi: 10.3109/17518423.2013.792298. X-123869515
3017 Baek JH, Whitfield D, Howlett D, . Unfolded protein response is activated in Lewy body dementias. Neuropathol Appl Neurobiol. 2015 Jul 23 doi: 10.1111/nan.12260. X-1
3018 Baggio G, van Lambalgen M, Hagoort P. Logic as Marr’s Computational Level: Four Case Studies. Top Cogn Sci. 2015 Apr;7(2):287–98. doi: 10.1111/tops.12125. X-125417838
3019 Baghani HR, Aghamiri SM, Mahdavi SR, . Comparing the dosimetric characteristics of the electron beam from dedicated intraoperative and conventional radiotherapy accelerators. J Appl Clin Med Phys. 2015;16(2):5017. doi: 10.1120/jacmp.v16i2.5017. X-126103175
3020 Bahta L, Ashkir A. Addressing MMR Vaccine Resistance in Minnesota’s Somali Community. Minn Med. 2015 Oct;98(10):33–6. X-1
3021 Bailey KM, Blair KC. Feasibility and potential efficacy of the family-centered Prevent-Teach-Reinforce model with families of children with developmental disorders. Res Dev Disabil. 2015 Oct 6;47:218–33. doi: 10.1016/j.ridd.2015.09.019. X-1, X-3, X-426451882
3022 Baker EK, Richdale AL. Sleep Patterns in Adults with a Diagnosis of High-Functioning Autism Spectrum Disorder. Sleep. 2015 Jul 24. X-1
3023 Baker JK, Fenning RM, Howland MA, . Brief Report: A Pilot Study of Parent-Child Biobehavioral Synchrony in Autism Spectrum Disorder. J Autism Dev Disord. 2015 Jul 17 doi: 10.1007/s10803-015-2528-0. X-1
3024 Baker K, Scerif G, Astle DE, . Psychopathology and cognitive performance in individuals with membrane-associated guanylate kinase mutations: a functional network phenotyping study. J Neurodev Disord. 2015;7(1):8. doi: 10.1186/s11689-015-9105-x. X-125802558
3025 Bakri MH, Ismail EA, Ali MS, . Behavioral and emotional effects of repeated general anesthesia in young children. Saudi J Anaesth. 2015 Apr–Jun;9(2):161–6. doi: 10.4103/1658-354x.152843. X-125829904
3026 Bal VH, Kim SH, Cheong D, . Daily living skills in individuals with autism spectrum disorder from 2 to 21 years of age. Autism. 2015 Oct;19(7):774–84. doi: 10.1177/1362361315575840. X-125922445
3027 Bal VH, Lord C. Replication of Standardized ADOS Domain Scores in the Simons Simplex Collection. Autism Res. 2015 Oct;8(5):583–92. doi: 10.1002/aur.1474. X-125712123
3028 Balardin JB, Comfort WE, Daly E, . Decreased centrality of cortical volume covariance networks in autism spectrum disorders. J Psychiatr Res. 2015 Oct;69:142–9. doi: 10.1016/j.jpsychires.2015.08.003. X-126343606
3029 Baldwin PR, Curtis KN, Patriquin MA, . Identifying diagnostically-relevant resting state brain functional connectivity in the ventral posterior complex via genetic data mining in autism spectrum disorder. Autism Res. 2015 Oct 9 doi: 10.1002/aur.1559. X-1
3030 Banire B, Jomhari N, Ahmad R. Visual Hybrid Development Learning System (VHDLS) Framework for Children with Autism. J Autism Dev Disord. 2015 Oct;45(10):3069–84. doi: 10.1007/s10803-015-2469-7. X-1, X-325997598
3031 Baranek GT, Watson LR, Turner-Brown L, . Preliminary efficacy of adapted responsive teaching for infants at risk of autism spectrum disorder in a community sample. Autism Res Treat. 2015;2015:386951. doi: 10.1155/2015/386951. X-125648749
3032 Barbeau EB, Meilleur AA, Zeffiro TA, . Comparing Motor Skills in Autism Spectrum Individuals With and Without Speech Delay. Autism Res. 2015 Mar 29 doi: 10.1002/aur.1483. X-1
3033 Barber C. Old age and people on the autism spectrum: a focus group perspective. Br J Nurs. 2015 Nov 26–Dec 9;24(21):1054–7. doi: 10.12968/bjon.2015.24.21.1054. X-126618675
3034 Baribeau DA, Doyle-Thomas KA, Dupuis A, . Examining and comparing social perception abilities across childhood-onset neurodevelopmental disorders. J Am Acad Child Adolesc Psychiatry. 2015 Jun;54(6):479–86.e1. doi: 10.1016/j.jaac.2015.03.016. X-126004663
3035 Barnard-Brak L, Davis TN, Schmidt M, . Effects associated with on- and off-label stimulant treatment of core autism and ADHD symptoms exhibited by children with autism spectrum disorder. Dev Neurorehabil. 2015 Aug 24:1–8. doi: 10.3109/17518423.2014.904949. X-3
3036 Baron-Cohen S, Auyeung B, Norgaard-Pedersen B, . Elevated fetal steroidogenic activity in autism. Mol Psychiatry. 2015 Mar;20(3):369–76. doi: 10.1038/mp.2014.48. X-124888361
3037 Baronio D, Castro K, Gonchoroski T, . Effects of an H3R antagonist on the animal model of autism induced by prenatal exposure to valproic acid. PLoS One. 2015;10(1):e0116363. doi: 10.1371/journal.pone.0116363. X-125560049
3038 Barrett B, Mosweu I, Jones CR, . Comparing service use and costs among adolescents with autism spectrum disorders, special needs and typical development. Autism. 2015 Jul;19(5):562–9. doi: 10.1177/1362361314536626. X-124913778
3039 Barrett SL, Uljarevic M, Baker EK, . The Adult Repetitive Behaviours Questionnaire-2 (RBQ-2A): A Self-Report Measure of Restricted and Repetitive Behaviours. J Autism Dev Disord. 2015 Nov;45(11):3680–92. doi: 10.1007/s10803-015-2514-6. X-126155763
3040 Barua S, Kuizon S, Chadman KK, . Microarray analysis reveals higher gestational folic Acid alters expression of genes in the cerebellum of mice offspring-a pilot study. Brain Sci. 2015;5(1):14–31. doi: 10.3390/brainsci5010014. X-125629700
3041 Bath E, Reba-Harrelson L, Peace R, . Correlates of Competency to Stand Trial Among Youths Admitted to a Juvenile Mental Health Court. J Am Acad Psychiatry Law. 2015 Sep;43(3):329–39. X-126438811
3042 Batool SS, Khurshid S. Factors Associated with Stress Among Parents of Children with Autism. J Coll Physicians Surg Pak. 2015 Oct;25(10):752–6. doi: 10.2015/jcpsp.752756. X-126454393
3043 Baucum AJ, 2nd, Shonesy BC, Rose KL, . Quantitative proteomics analysis of CaMKII phosphorylation and the CaMKII interactome in the mouse forebrain. ACS Chem Neurosci. 2015 Apr 15;6(4):615–31. doi: 10.1021/cn500337u. X-125650780
3044 Bauer NS, Carroll AE, Saha C, . Computer Decision Support Changes Physician Practice But Not Knowledge Regarding Autism Spectrum Disorders. Appl Clin Inform. 2015;6(3):454–65. doi: 10.4338/aci-2014-09-ra-0084. X-126448791
3045 Baum KT, Shear PK, Howe SR, . A comparison of WISC-IV and SB-5 intelligence scores in adolescents with autism spectrum disorder. Autism. 2015 Aug;19(6):736–45. doi: 10.1177/1362361314554920. X-125398894
3046 Bawaskar HS, Bawaskar PH, Bawaskar PH. RBC acetyl cholinesterase: A poor man’s early diagnostic biomarker for familial alzheimer’s and Parkinson’s disease dementia. J Neurosci Rural Pract. 2015 Jan;6(1):33–8. doi: 10.4103/0976-3147.143187. X-125552849
3047 Bazalova-Carter M, Liu M, Palma B, . Comparison of film measurements and Monte Carlo simulations of dose delivered with very high-energy electron beams in a polystyrene phantom. Med Phys. 2015 Apr;42(4):1606–13. doi: 10.1118/1.4914371. X-125832051
3048 Beales DL. Biome depletion in conjunction with evolutionary mismatches could play a role in the etiology of neurofibromatosis 1. Med Hypotheses. 2015 Apr;84(4):305–14. doi: 10.1016/j.mehy.2015.01.014. X-125665856
3049 Bean Ellawadi A, McGregor KK. Children with ASD can use gaze to map new words. Int J Lang Commun Disord. 2015 Sep 6 doi: 10.1111/1460-6984.12192. X-1
3050 Bearss K, Burrell TL, Stewart L, . Parent Training in Autism Spectrum Disorder: What’s in a Name? Clin Child Fam Psychol Rev. 2015 Jun;18(2):170–82. doi: 10.1007/s10567-015-0179-5. X-125722072
3051 Bearss K, Johnson C, Smith T, . Effect of parent training vs parent education on behavioral problems in children with autism spectrum disorder: a randomized clinical trial. Jama. 2015 Apr 21;313(15):1524–33. doi: 10.1001/jama.2015.3150. X-125898050
3052 Bearss K, Taylor CA, Aman MG, . Using qualitative methods to guide scale development for anxiety in youth with autism spectrum disorder. Autism. 2015 Sep 22 doi: 10.1177/1362361315601012. X-1
3053 Bebko JM, Rhee T, McMorris CA, . Spontaneous strategy use in children with autism spectrum disorder: the roles of metamemory and language skills. Front Psychol. 2015;6:182. doi: 10.3389/fpsyg.2015.00182. X-1, X-325788890
3054 Begeer S, Fink E, van der Meijden S, . Bullying-related behaviour in a mainstream high school versus a high school for autism: Self-report and peer-report. Autism. 2015 Aug 3 doi: 10.1177/1362361315597525. X-1
3055 Begeer S, Howlin P, Hoddenbach E, . Effects and Moderators of a Short Theory of Mind Intervention for Children with Autism Spectrum Disorder: A Randomized Controlled Trial. Autism Res. 2015 Apr 6 doi: 10.1002/aur.1489. X-1
3056 Bellando J, Fussell JJ, Lopez M. Autism Speaks Toolkits: Resources for Busy Physicians. Clin Pediatr (Phila). 2015 Jul 6 doi: 10.1177/0009922815594587. X-1
3057 Benjamin DP, McDuffie AS, Thurman AJ, . Effect of speaker gaze on word learning in fragile X syndrome: a comparison with nonsyndromic autism spectrum disorder. J Speech Lang Hear Res. 2015 Apr;58(2):383–95. doi: 10.1044/2015_jslhr-l-14-0136. X-125629603
3058 Bennabi M, Delorme R, Oliveira J, . Dectin-1 Polymorphism: A Genetic Disease Specifier in Autism Spectrum Disorders? PLoS One. 2015;10(9):e0137339. doi: 10.1371/journal.pone.0137339. X-126352598
3059 Bennett JA, Germani T, Haqq AM, . Autism spectrum disorder in Prader-Willi syndrome: A systematic review. Am J Med Genet A. 2015 Aug 29 doi: 10.1002/ajmg.a.37286. X-1
3060 Bent CA, Dissanayake C, Barbaro J. Mapping the diagnosis of autism spectrum disorders in children aged under 7 years in Australia, 2010–2012. Med J Aust. 2015 Apr 6;202(6):317–20. X-125832158
3061 Benvenuto A, Battan B, Benassi F, . Effectiveness of community-based treatment on clinical outcome in children with autism spectrum disorders: An Italian prospective study. Dev Neurorehabil. 2015 Aug 24:1–9. doi: 10.3109/17518423.2013.864716. X-3
3062 Berens JC, Peacock C. Implementation of an academic adult primary care clinic for adolescents and young adults with complex, chronic childhood conditions. J Pediatr Rehabil Med. 2015;8(1):3–12. doi: 10.3233/prm-150313. X-125737343
3063 Bergmann T, Sappok T, Diefenbacher A, . Music-based Autism Diagnostics (MUSAD) - A newly developed diagnostic measure for adults with intellectual developmental disabilities suspected of autism. Res Dev Disabil. 2015 Aug–Sep;43–44:123–35. doi: 10.1016/j.ridd.2015.05.011. X-1
3064 Berry RC, Novak P, Withrow N, . Nutrition Management of Gastrointestinal Symptoms in Children with Autism Spectrum Disorder: Guideline from an Expert Panel. J Acad Nutr Diet. 2015 Dec;115(12):1919–27. doi: 10.1016/j.jand.2015.05.016. X-126164551
3065 Besag FM. Current controversies in the relationships between autism and epilepsy. Epilepsy Behav. 2015 Jun;47:143–6. doi: 10.1016/j.yebeh.2015.05.032. X-1, X-226091860
3066 Bhandari R, Kuhad A. Neuropsychopharmacotherapeutic efficacy of curcumin in experimental paradigm of autism spectrum disorders. Life Sci. 2015 Sep 23 doi: 10.1016/j.lfs.2015.09.012. X-1
3067 Bijl N, Thys C, Wittevrongel C, . Platelet studies in autism spectrum disorder patients and first-degree relatives. Mol Autism. 2015;6:57. doi: 10.1186/s13229-015-0051-y. X-126500752
3068 Bilaver LA, Cushing LS, Cutler AT. Prevalence and Correlates of Educational Intervention Utilization Among Children with Autism Spectrum Disorder. J Autism Dev Disord. 2015 Sep 21 doi: 10.1007/s10803-015-2598-z. X-1
3069 Billeci L, Tonacci A, Tartarisco G, . Association Between Atopic Dermatitis and Autism Spectrum Disorders: A Systematic Review. Am J Clin Dermatol. 2015 Oct;16(5):371–88. doi: 10.1007/s40257-015-0145-5. X-126254000
3070 Bink M, Popma A, Bongers IL, . Cardiac reactivity and stimulant use in adolescents with autism spectrum disorders with comorbid ADHD versus ADHD. J Autism Dev Disord. 2015 Feb;45(2):481–94. doi: 10.1007/s10803-013-1929-1. X-124005985
3071 Bink M, van Boxtel GJ, Popma A, . EEG theta and beta power spectra in adolescents with ADHD versus adolescents with ASD + ADHD. Eur Child Adolesc Psychiatry. 2015 Aug;24(8):873–86. doi: 10.1007/s00787-014-0632-x. X-125374034
3072 Bisgaard AM, Schonewolf-Greulich B, Ravn K, . Is it possible to diagnose Rett syndrome before classical symptoms become obvious? Review of 24 Danish cases born between 2003 and 2012. Eur J Paediatr Neurol. 2015 Nov;19(6):679–87. doi: 10.1016/j.ejpn.2015.07.004. X-126228846
3073 Bishop JR, Najjar F, Rubin LH, . Escitalopram pharmacogenetics: CYP2C19 relationships with dosing and clinical outcomes in autism spectrum disorder. Pharmacogenet Genomics. 2015 Nov;25(11):548–54. doi: 10.1097/fpc.0000000000000173. X-326313485
3074 Bishop-Fitzpatrick L, Mazefsky CA, Minshew NJ, . The relationship between stress and social functioning in adults with autism spectrum disorder and without intellectual disability. Autism Res. 2015 Apr;8(2):164–73. doi: 10.1002/aur.1433. X-125524571
3075 Blackmon K, Bluvstein J, MacAllister WS, . Treatment Resistant Epilepsy in Autism Spectrum Disorder: Increased Risk for Females. Autism Res. 2015 Jun 26 doi: 10.1002/aur.1514. X-1
3076 Blanche EI, Diaz J, Barretto T, . Caregiving Experiences of Latino Families With Children With Autism Spectrum Disorder. Am J Occup Ther. 2015 Sep–Oct;69(5):6905185010p1–11. doi: 10.5014/ajot.2015.017848. X-1
3077 Blasi A, Lloyd-Fox S, Sethna V, . Atypical processing of voice sounds in infants at risk for autism spectrum disorder. Cortex. 2015 Oct;71:122–33. doi: 10.1016/j.cortex.2015.06.015. X-126200892
3078 Blomqvist M, Bejerot S, Dahllof G. A cross-sectional study on oral health and dental care in intellectually able adults with autism spectrum disorder. BMC Oral Health. 2015;15:81. doi: 10.1186/s12903-015-0065-z. X-126174171
3079 Blumberg SJ, Zablotsky B, Avila RM, . Diagnosis lost: Differences between children who had and who currently have an autism spectrum disorder diagnosis. Autism. 2015 Oct 20 doi: 10.1177/1362361315607724. X-1
3080 Bodner KE, Engelhardt CR, Minshew NJ, . Making Inferences: Comprehension of Physical Causality, Intentionality, and Emotions in Discourse by High-Functioning Older Children, Adolescents, and Adults with Autism. J Autism Dev Disord. 2015 Sep;45(9):2721–33. doi: 10.1007/s10803-015-2436-3. X-125821925
3081 Boets B, Verhoeven J, Wouters J, . Fragile spectral and temporal auditory processing in adolescents with autism spectrum disorder and early language delay. J Autism Dev Disord. 2015 Jun;45(6):1845–57. doi: 10.1007/s10803-014-2341-1. X-125503681
3082 Bogliacino F, Parra Forero IA. Behaviourally designed treatments that increase willingness to treatment from families with children suffering from autism spectrum disorder. J Epidemiol Community Health. 2015 Oct;69(10):958–62. doi: 10.1136/jech-2015-205505. X-125903754
3083 Bolling DZ, Pelphrey KA, Vander Wyk BC. Trait-level temporal lobe hypoactivation to social exclusion in unaffected siblings of children and adolescents with autism spectrum disorders. Dev Cogn Neurosci. 2015 Jun;13:75–83. doi: 10.1016/j.dcn.2015.04.007. X-126011751
3084 Bolte S, Ciaramidaro A, Schlitt S, . Training-induced plasticity of the social brain in autism spectrum disorder. Br J Psychiatry. 2015 Aug;207(2):149–57. doi: 10.1192/bjp.bp.113.143784. X-125792694
3085 Bone D, Goodwin MS, Black MP, . Applying machine learning to facilitate autism diagnostics: pitfalls and promises. J Autism Dev Disord. 2015 May;45(5):1121–36. doi: 10.1007/s10803-014-2268-6. X-125294649
3086 Bonete S, Calero MD, Fernandez-Parra A. Group training in interpersonal problem-solving skills for workplace adaptation of adolescents and adults with Asperger syndrome: a preliminary study. Autism. 2015 May;19(4):409–20. doi: 10.1177/1362361314522354. X-124569569
3087 Bora E, Bartholomeusz C, Pantelis C. Meta-analysis of Theory of Mind (ToM) impairment in bipolar disorder. Psychol Med. 2015 Oct 12:1–12. doi: 10.1017/s0033291715001993. X-1
3088 Borders CM, Bock SJ, Szymanski C. Teacher ratings of evidence-based practices from the field of autism. J Deaf Stud Deaf Educ. 2015 Jan;20(1):91–100. doi: 10.1093/deafed/enu033. X-125316908
3089 Borgi M, Loliva D, Cerino S, . Effectiveness of a Standardized Equine-Assisted Therapy Program for Children with Autism Spectrum Disorder. J Autism Dev Disord. 2015 Jul 26 doi: 10.1007/s10803-015-2530-6. X-1
3090 Borroni B, Premi E, Formenti A, . Structural and functional imaging study in dementia with Lewy bodies and Parkinson’s disease dementia. Parkinsonism Relat Disord. 2015 Sep;21(9):1049–55. doi: 10.1016/j.parkreldis.2015.06.013. X-126109553
3091 Bos DJ, Merchan-Naranjo J, Martinez K, . Reduced Gyrification Is Related to Reduced Interhemispheric Connectivity in Autism Spectrum Disorders. J Am Acad Child Adolesc Psychiatry. 2015 Aug;54(8):668–76. doi: 10.1016/j.jaac.2015.05.011. X-126210336
3092 Bottema-Beutel K, Li Z. Adolescent judgments and reasoning about the failure to include peers with social disabilities. J Autism Dev Disord. 2015 Jun;45(6):1873–86. doi: 10.1007/s10803-014-2348-7. X-125575622
3093 Bottema-Beutel K, Mullins TS, Harvey MN, . Avoiding the “brick wall of awkward”: Perspectives of youth with autism spectrum disorder on social-focused intervention practices. Autism. 2015 Apr 16 doi: 10.1177/1362361315574888. X-1
3094 Bottema-Beutel K, White R. By the Book: An Analysis of Adolescents with Autism Spectrum Condition Co-constructing Fictional Narratives with Peers. J Autism Dev Disord. 2015 Jul 15 doi: 10.1007/s10803-015-2524-4. X-1
3095 Boudreau BA, Vladescu JC, Kodak TM, . A comparison of differential reinforcement procedures with children with autism. J Appl Behav Anal. 2015 Jul 14 doi: 10.1002/jaba.232. X-3, X-4
3096 Bowers K, Wink LK, Pottenger A, . Phenotypic differences in individuals with autism spectrum disorder born preterm and at term gestation. Autism. 2015 Aug;19(6):758–63. doi: 10.1177/1362361314547366. X-125192860
3097 Bowler DM, Gaigg SB, Gardiner JM. Brief Report: The Role of Task Support in the Spatial and Temporal Source Memory of Adults with Autism Spectrum Disorder. J Autism Dev Disord. 2015 Aug;45(8):2613–7. doi: 10.1007/s10803-015-2378-9. X-125694363
3098 Braat S, D’Hulst C, Heulens I, . The GABAA receptor is an FMRP target with therapeutic potential in fragile X syndrome. Cell Cycle. 2015 Sep 17;14(18):2985–95. doi: 10.4161/15384101.2014.989114. X-125790165
3099 Braddock BA, Twyman KA, Garrity MR, . A Few Close Friends: The Pediatrician’s Role in the Management of Social Skills Deficits in Adolescent Children. Clin Pediatr (Phila). 2015 Oct;54(12):1192–9. doi: 10.1177/0009922815570619. X-125676832
3100 Bradshaw J, Steiner AM, Gengoux G, . Feasibility and effectiveness of very early intervention for infants at-risk for autism spectrum disorder: a systematic review. J Autism Dev Disord. 2015 Mar;45(3):778–94. doi: 10.1007/s10803-014-2235-2. X-1, X-225218848
3101 Brady NC, Storkel HL, Bushnell P, . Investigating a Multimodal Intervention for Children with Limited Expressive Vocabularies Associated with Autism. Am J Speech Lang Pathol. 2015 Apr 24 doi: 10.1044/2015_ajslp-14-0093. X-3
3102 Braida D, Ponzoni L, Matteoli M, . Different attentional abilities among inbred mice strains using virtual object recognition task (VORT): SNAP25 mice as a model of attentional deficit. Behav Brain Res. 2015 Aug 20 doi: 10.1016/j.bbr.2015.08.016. X-1
3103 Brand S, Jossen S, Holsboer-Trachsler E, . Impact of aerobic exercise on sleep and motor skills in children with autism spectrum disorders - a pilot study. Neuropsychiatr Dis Treat. 2015;11:1911–20. doi: 10.2147/ndt.s85650. X-326346856
3104 Brandwein AB, Foxe JJ, Butler JS, . Neurophysiological indices of atypical auditory processing and multisensory integration are associated with symptom severity in autism. Journal of Autism and Developmental Disorders. 2015 2015-12-09;45(1):230–44. doi: 10.1002/aur.56. http://dx.doi.org/10.1007/s10803-014-2212-9; 2014-40415-001. X-125245785
3105 Breau LM, Clark B, Scott O, . Social communication features in children following moderate to severe acquired brain injury: a cross-sectional pilot study. J Child Neurol. 2015 Apr;30(5):588–94. doi: 10.1177/0883073814528282. X-124659736
3106 Bremer E, Balogh R, Lloyd M. Effectiveness of a fundamental motor skill intervention for 4-year-old children with autism spectrum disorder: A pilot study. Autism. 2015 Nov;19(8):980–91. doi: 10.1177/1362361314557548. X-425432505
3107 Brenes JC, Lackinger M, Hoglinger GU, . Differential effects of social and physical environmental enrichment on brain plasticity, cognition, and ultrasonic communication in rats. J Comp Neurol. 2015 Jul 1 doi: 10.1002/cne.23842. X-1
3108 Brezis RS, Weisner TS, Daley TC, . Parenting a child with autism in India: narratives before and after a parent-child intervention program. Cult Med Psychiatry. 2015 Jun;39(2):277–98. doi: 10.1007/s11013-015-9434-y. X-125739529
3109 Brian JA, Bryson SE, Zwaigenbaum L. Autism spectrum disorder in infancy: developmental considerations in treatment targets. Curr Opin Neurol. 2015 Apr;28(2):117–23. doi: 10.1097/wco.0000000000000182. X-1, x-225695137
3110 Brigandi SA, Shao H, Qian SY, . Autistic children exhibit decreased levels of essential Fatty acids in red blood cells. Int J Mol Sci. 2015;16(5):10061–76. doi: 10.3390/ijms160510061. X-125946342
3111 Brix MK, Ersland L, Hugdahl K, . “Brain MR spectroscopy in autism spectrum disorder-the GABA excitatory/inhibitory imbalance theory revisited”. Front Hum Neurosci. 2015;9:365. doi: 10.3389/fnhum.2015.00365. X-126157380
3112 Broekhof E, Ketelaar L, Stockmann L, . The Understanding of Intentions, Desires and Beliefs in Young Children with Autism Spectrum Disorder. J Autism Dev Disord. 2015 Jul;45(7):2035–45. doi: 10.1007/s10803-015-2363-3. X-125636676
3113 Brondino N, Fusar-Poli L, Panisi C, . Pharmacological Modulation of GABA Function in Autism Spectrum Disorders: A Systematic Review of Human Studies. J Autism Dev Disord. 2015 Oct 6 doi: 10.1007/s10803-015-2619-y. X-2
3114 Brosnan M, Johnson H, Grawmeyer B, . Emotion recognition in animated compared to human stimuli in adolescents with autism spectrum disorder. J Autism Dev Disord. 2015 Jun;45(6):1785–96. doi: 10.1007/s10803-014-2338-9. X-125567528
3115 Brosnan M, Mills E. The effect of diagnostic labels on the affective responses of college students towards peers with ‘Asperger’s Syndrome’ and ‘Autism Spectrum Disorder’. Autism. 2015 Jun 4 doi: 10.1177/1362361315586721. X-1
3116 Brown A, Crowe L, Beauchamp MH, . Neurodevelopmental profiles of children with glutaric aciduria type I diagnosed by newborn screening: a follow-up case series. JIMD Rep. 2015;18:125–34. doi: 10.1007/8904_2014_360. X-125503300
3117 Bruce SM, Borders C. Communication and Language in Learners Who Are Deaf and Hard of Hearing With Disabilities: Theories, Research, and Practice. Am Ann Deaf. 2015;160(4):368–84. doi: 10.1353/aad.2015.0035. X-126497075
3118 Brugha TS, Doos L, Tempier A, . Outcome measures in intervention trials for adults with autism spectrum disorders; a systematic review of assessments of core autism features and associated emotional and behavioural problems. Int J Methods Psychiatr Res. 2015 Jun;24(2):99–115. doi: 10.1002/mpr.1466. X-126077193
3119 Bruining H, Matsui A, Oguro-Ando A, . Genetic Mapping in Mice Reveals the Involvement of Pcdh9 in Long-Term Social and Object Recognition and Sensorimotor Development. Biol Psychiatry. 2015 Oct 1;78(7):485–95. doi: 10.1016/j.biopsych.2015.01.017. X-125802080
3120 Bruining H, Passtoors L, Goriounova N, . Paradoxical Benzodiazepine Response: A Rationale for Bumetanide in Neurodevelopmental Disorders? Pediatrics. 2015 Aug;136(2):e539–43. doi: 10.1542/peds.2014-4133. X-1, X-3, X-426216321
3121 Brunner D, Kabitzke P, He D, . Comprehensive Analysis of the 16p11.2 Deletion and Null Cntnap2 Mouse Models of Autism Spectrum Disorder. PLoS One. 2015;10(8):e0134572. doi: 10.1371/journal.pone.0134572. X-126273832
3122 Brunsdon VE, Colvert E, Ames C, . Exploring the cognitive features in children with autism spectrum disorder, their co-twins, and typically developing children within a population-based sample. J Child Psychol Psychiatry. 2015 Aug;56(8):893–902. doi: 10.1111/jcpp.12362. X-125418509
3123 Bryn V, Halvorsen B, Ueland T, . Brain derived neurotrophic factor (BDNF) and autism spectrum disorders (ASD) in childhood. Eur J Paediatr Neurol. 2015 Jul;19(4):411–4. doi: 10.1016/j.ejpn.2015.03.005. X-125847750
3124 Bukala M, Hu MY, Lee R, . The effects of work-reinforcer schedules on performance and preference in students with autism. J Appl Behav Anal. 2015 Spring;48(1):215–20. doi: 10.1002/jaba.188. X-125688839
3125 Bunai Y, Ishii A, Akaza K, . A case of sudden death after Japanese encephalitis vaccination. Leg Med (Tokyo). 2015 Jul;17(4):279–82. doi: 10.1016/j.legalmed.2015.03.003. X-125819538
3126 Burckley E, Tincani M, Guld Fisher A. An iPad-based picture and video activity schedule increases community shopping skills of a young adult with autism spectrum disorder and intellectual disability. Dev Neurorehabil. 2015 Apr;18(2):131–6. doi: 10.3109/17518423.2014.945045. X-125084013
3127 Burke MM, Goldman SE. Identifying the associated factors of mediation and due process in families of students with autism spectrum disorder. J Autism Dev Disord. 2015 May;45(5):1345–53. doi: 10.1007/s10803-014-2294-4. X-125374132
3128 Burkett K, Morris E, Manning-Courtney P, . African American Families on Autism Diagnosis and Treatment: The Influence of Culture. J Autism Dev Disord. 2015 Oct;45(10):3244–54. doi: 10.1007/s10803-015-2482-x. X-126055985
3129 Busch de Ahumada LC, Ahumada JL. Contacting a 19 month-old mute autistic girl: a clinical narrative. Int J Psychoanal. 2015 Feb;96(1):11–38. doi: 10.1111/1745-8315.12248. X-125294631
3130 Bush RA, Stahmer AC, Connelly CD. Exploring perceptions and use of the electronic health record by parents of children with autism spectrum disorder: A qualitative study. Health Informatics J. 2015 May 18 doi: 10.1177/1460458215581911. X-1
3131 Butler EE, Ward R, Ramsey R. Investigating the Relationship between Stable Personality Characteristics and Automatic Imitation. PLoS One. 2015;10(6):e0129651. doi: 10.1371/journal.pone.0129651. X-126079137
3132 Butler MG, Hossain W, Sulsona C, . Increased plasma chemokine levels in children with Prader-Willi syndrome. Am J Med Genet A. 2015 Mar;167a(3):563–71. doi: 10.1002/ajmg.a.36908. X-125691409
3133 Butler MG, McGuire AB, Masoud H, . Currently recognized genes for schizophrenia: High-resolution chromosome ideogram representation. Am J Med Genet B Neuropsychiatr Genet. 2015 Oct 13 doi: 10.1002/ajmg.b.32391. X-1
3134 Buzhardt J, Rusinko L, Heitzman-Powell L, . Exploratory Evaluation and Initial Adaptation of a Parent Training Program for Hispanic Families of Children with Autism. Fam Process. 2015 Mar 16 doi: 10.1111/famp.12146. X-1, X-2
3135 Byford S, Cary M, Barrett B, . Cost-effectiveness analysis of a communication-focused therapy for pre-school children with autism: results from a randomised controlled trial. BMC Psychiatry. 2015;15:316. doi: 10.1186/s12888-015-0700-x. X-126691535
3136 Byrge L, Dubois J, Tyszka JM, . Idiosyncratic brain activation patterns are associated with poor social comprehension in autism. J Neurosci. 2015 Apr 8;35(14):5837–50. doi: 10.1523/jneurosci.5182-14.2015. X-1, X-425855192
3137 Cagetti MG, Mastroberardino S, Campus G, . Dental care protocol based on visual supports for children with autism spectrum disorders. Med Oral Patol Oral Cir Bucal. 2015;20(5):e598–604. X-126241453
3138 Calarge CA, Ziegler EE, Del Castillo N, . Iron homeostasis during risperidone treatment in children and adolescents. J Clin Psychiatry. 2015 Aug 4 doi: 10.4088/JCP.14m09258. X-1, X-3
3139 Calderon J, Bellinger DC. Executive function deficits in congenital heart disease: why is intervention important? Cardiol Young. 2015 Oct;25(7):1238–46. doi: 10.1017/s1047951115001134. X-1, X-226082199
3140 Calderoni S, Fantozzi P, Balboni G, . The impact of internalizing symptoms on autistic traits in adolescents with restrictive anorexia nervosa. Neuropsychiatr Dis Treat. 2015;11:75–85. doi: 10.2147/ndt.s73235. X-125609969
3141 Campbell JE, Morgan M, Barnett V, . Handheld Devices and Video Modeling to Enhance the Learning of Self-Help Skills in Adolescents With Autism Spectrum Disorder. OTJR (Thorofare N J). 2015 Apr;35(2):95–100. X-1, X-3, X-426460472
3142 Campbell SB, Leezenbaum NB, Schmidt EN, . Concern for Another’s Distress in Toddlers at High and Low Genetic Risk for Autism Spectrum Disorder. J Autism Dev Disord. 2015 Nov;45(11):3594–605. doi: 10.1007/s10803-015-2505-7. X-126093390
3143 Canal CE, Felsing DE, Liu Y, . An Orally Active Phenylaminotetralin-Chemotype Serotonin 5-HT7 and 5-HT1A Receptor Partial Agonist that Corrects Motor Stereotypy in Mouse Models. ACS Chem Neurosci. 2015 Jul 15;6(7):1259–70. doi: 10.1021/acschemneuro.5b00099. X-126011730
3144 Canal-Bedia R, Garcia-Primo P, Hernandez-Fabian A, . [From early detection to early care: intervention strategies based on prospective screening]. Rev Neurol. 2015 Feb 25;60(Suppl 1):S25–9. X-125726819
3145 Canitano R. Mood Stabilizers in Children and Adolescents With Autism Spectrum Disorders. Clin Neuropharmacol. 2015 Sep–Oct;38(5):177–82. doi: 10.1097/wnf.0000000000000096. X-126366961
3146 Canitano R, Bozzi Y. New treatment perspectives in autism spectrum disorders. Front Pediatr. 2015;3:22. doi: 10.3389/fped.2015.00022. X-1, X-2, X-325853112
3147 Caplette L, Desroches P, Wicker B, . Autistic and neurotypical subjects extract spatial frequencies differently. J Vis. 2015 Sep 1;15(12):478. doi: 10.1167/15.12.478. X-1
3148 Carbon M, Kapoor S, Sheridan E, . Neuromotor Adverse Effects in 342 Youth During 12 Weeks of Naturalistic Treatment With 5 Second-Generation Antipsychotics. J Am Acad Child Adolesc Psychiatry. 2015 Sep;54(9):718–27.e3. doi: 10.1016/j.jaac.2015.06.015. X-126299293
3149 Carmichael JA, Kubas HA, Carlson HL, . Reconsidering “inattention” in attention-deficit hyperactivity disorder: implications for neuropsychological assessment and intervention. Appl Neuropsychol Child. 2015;4(2):97–105. doi: 10.1080/21622965.2015.1005481. X-125748971
3150 Carmo JC, Duarte E, Pinho S, . Preserved Proactive Interference in Autism Spectrum Disorder. J Autism Dev Disord. 2015 Jul 26 doi: 10.1007/s10803-015-2540-4. X-1
3151 Carmo JC, Duarte E, Pinho S, . Verbal fluency as a function of time in autism spectrum disorder: An impairment of initiation processes? J Clin Exp Neuropsychol. 2015 Sep;37(7):710–21. doi: 10.1080/13803395.2015.1062082. X-126207691
3152 Carper RA, Solders S, Treiber JM, . Corticospinal Tract Anatomy and Functional Connectivity of Primary Motor Cortex in Autism. J Am Acad Child Adolesc Psychiatry. 2015 Oct;54(10):859–67. doi: 10.1016/j.jaac.2015.07.007. X-126407496
3153 Carr T, Shih W, Lawton K, . The relationship between treatment attendance, adherence, and outcome in a caregiver-mediated intervention for low-resourced families of young children with autism spectrum disorder. Autism. 2015 Aug 19 doi: 10.1177/1362361315598634. X-1, X-3
3154 Carre A, Chevallier C, Robel L, . Tracking Social Motivation Systems Deficits: The Affective Neuroscience View of Autism. J Autism Dev Disord. 2015 Oct;45(10):3351–63. doi: 10.1007/s10803-015-2498-2. X-126123007
3155 Carroll RA, Joachim BT, St Peter CC, . A comparison of error-correction procedures on skill acquisition during discrete-trial instruction. J Appl Behav Anal. 2015 Summer;48(2):257–73. doi: 10.1002/jaba.205. X-125913105
3156 Carroll RA, Kodak T. Using Instructive Feedback to Increase Response Variability During Intraverbal Training for Children with Autism Spectrum Disorder. Anal Verbal Behav. 2015 Oct;31(2):183–99. doi: 10.1007/s40616-015-0039-x. X-3, X-427606211
3157 Casanova MF, Sokhadze E, Opris I, . Autism spectrum disorders: linking neuropathological findings to treatment with transcranial magnetic stimulation. Acta Paediatr. 2015 Apr;104(4):346–55. doi: 10.1111/apa.12943. X-125626149
3158 Cascio CJ, Gu C, Schauder KB, . Somatosensory Event-Related Potentials and Association with Tactile Behavioral Responsiveness Patterns in Children with ASD. Brain Topogr. 2015 Nov;28(6):895–903. doi: 10.1007/s10548-015-0439-1. X-126016951
3159 Cascio MA. Rigid therapies, rigid minds: italian professionals’ perspectives on autism interventions. Cult Med Psychiatry. 2015 Jun;39(2):235–53. doi: 10.1007/s11013-015-9439-6. X-125743186
3160 Casenhiser DM, Binns A, McGill F, . Measuring and supporting language function for children with autism: evidence from a randomized control trial of a social-interaction-based therapy. J Autism Dev Disord. 2015 Mar;45(3):846–57. doi: 10.1007/s10803-014-2242-3. X-1, X-225234481
3161 Case-Smith J, Weaver LL, Fristad MA. A systematic review of sensory processing interventions for children with autism spectrum disorders. Autism: The International Journal of Research & Practice. 2015;19(2):133–48 16p. doi: 10.1177/1362361313517762. Language: English. Entry Date: 20150130. Revision Date: 20150710. Publication Type: Journal Article. X-1, X-224477447
3162 Casey AF, Quenneville-Himbeault G, Normore A, . A therapeutic skating intervention for children with autism spectrum disorder. Pediatr Phys Ther. 2015 Summer;27(2):170–7. doi: 10.1097/pep.0000000000000139. X-3, X-425822357
3163 Cash-Padgett T, Sawa A, Jaaro-Peled H. Increased stereotypy in conditional Cxcr4 knockout mice. Neurosci Res. 2015 Oct 13 doi: 10.1016/j.neures.2015.10.001. X-1
3164 Cassidy S, Mitchell P, Chapman P, . Processing of Spontaneous Emotional Responses in Adolescents and Adults with Autism Spectrum Disorders: Effect of Stimulus Type. Autism Res. 2015 Oct;8(5):534–44. doi: 10.1002/aur.1468. X-125735657
3165 Castro S, Pinto A. Matrix for assessment of activities and participation: Measuring functioning beyond diagnosis in young children with disabilities. Dev Neurorehabil. 2015 Jun;18(3):177–89. doi: 10.3109/17518423.2013.806963. X-123869963
3166 Cermak SA, Stein Duker LI, Williams ME, . Sensory Adapted Dental Environments to Enhance Oral Care for Children with Autism Spectrum Disorders: A Randomized Controlled Pilot Study. J Autism Dev Disord. 2015 Sep;45(9):2876–88. doi: 10.1007/s10803-015-2450-5. X-125931290
3167 Cermak SA, Stein Duker LI, Williams ME, . Feasibility of a sensory-adapted dental environment for children with autism. Am J Occup Ther. 2015 May–Jun;69(3):6903220020p1–p10. doi: 10.5014/ajot.2015.013714. X-1
3168 Cermakova P, Johnell K, Fastbom J, . Cardiovascular Diseases in approximately 30,000 Patients in the Swedish Dementia Registry. J Alzheimers Dis. 2015 Sep 16 doi: 10.3233/jad-150499. X-1
3169 Cervantes PE, Matson JL. Comorbid Symptomology in Adults with Autism Spectrum Disorder and Intellectual Disability. J Autism Dev Disord. 2015 Aug 9 doi: 10.1007/s10803-015-2553-z. X-1
3170 Chakrabarti B, Persico A, Battista N, . Endocannabinoid Signaling in Autism. Neurotherapeutics. 2015 Oct;12(4):837–47. doi: 10.1007/s13311-015-0371-9. X-126216231
3171 Chakraborty A, Chakrabarti B. Is it me? Self-recognition bias across sensory modalities and its relationship to autistic traits. Mol Autism. 2015;6:20. doi: 10.1186/s13229-015-0016-1. X-125908952
3172 Chakraborty S, Thomas P, Bhatia T, . Assessment of severity of autism using the Indian scale for assessment of autism. Indian J Psychol Med. 2015 Apr–Jun;37(2):169–74. doi: 10.4103/0253-7176.155616. X-125969602
3173 Chaminade T, Rosset D, Da Fonseca D, . Anthropomorphic bias found in typically developing children is not found in children with autistic spectrum disorder. Autism: The International Journal of Research & Practice. 2015;19(2):248–51 4p. doi: 10.1177/1362361313512425. Language: English. Entry Date: 20150130. Revision Date: 20150710. Publication Type: Journal Article. X-124345879
3174 Chandler S, Howlin P, Simonoff E, . Emotional and behavioural problems in young children with autism spectrum disorder. Dev Med Child Neurol. 2015 Jun 16 doi: 10.1111/dmcn.12830. X-1
3175 Chandley MJ, Crawford JD, Szebeni A, . NTRK2 expression levels are reduced in laser captured pyramidal neurons from the anterior cingulate cortex in males with autism spectrum disorder. Mol Autism. 2015;6:28. doi: 10.1186/s13229-015-0023-2. X-126000162
3176 Chandrasekhar T, Sikich L. Challenges in the diagnosis and treatment of depression in autism spectrum disorders across the lifespan. Dialogues Clin Neurosci. 2015 Jun;17(2):219–27. X-1, X-226246795
3177 Chang L, Ho SY, Lee TF, . Calibration of EBT2 film using a red-channel PDD method in combination with a modified three-channel technique. Med Phys. 2015 Oct;42(10):5838. doi: 10.1118/1.4930253. X-126429258
3178 Chantiluke K, Barrett N, Giampietro V, . Inverse Effect of Fluoxetine on Medial Prefrontal Cortex Activation During Reward Reversal in ADHD and Autism. Cereb Cortex. 2015 Jul;25(7):1757–70. doi: 10.1093/cercor/bht365. X-124451919
3179 Chantiluke K, Barrett N, Giampietro V, . Disorder-dissociated effects of fluoxetine on brain function of working memory in attention deficit hyperactivity disorder and autism spectrum disorder. Psychol Med. 2015 Apr;45(6):1195–205. doi: 10.1017/s0033291714002232. X-1, X-325292351
3180 Chantiluke K, Barrett N, Giampietro V, . Inverse fluoxetine effects on inhibitory brain activation in non-comorbid boys with ADHD and with ASD. Psychopharmacology (Berl). 2015 Jun;232(12):2071–82. doi: 10.1007/s00213-014-3837-2. X-125533997
3181 Chapman NH, Nato AQ, Jr., Bernier R, . Whole exome sequencing in extended families with autism spectrum disorder implicates four candidate genes. Hum Genet. 2015 Oct;134(10):1055–68. doi: 10.1007/s00439-015-1585-y. X-126204995
3182 Charman T, Baird G, Simonoff E, . Testing two screening instruments for autism spectrum disorder in UK community child health services. Dev Med Child Neurol. 2015 Aug 25 doi: 10.1111/dmcn.12874. X-1
3183 Charman T, Ricketts J, Dockrell JE, . Emotional and behavioural problems in children with language impairments and children with autism spectrum disorders. Int J Lang Commun Disord. 2015 Jan;50(1):84–93. doi: 10.1111/1460-6984.12116. X-125039810
3184 Chatterji P, Decker SL, Markowitz S. The effects of mandated health insurance benefits for autism on out-of-pocket costs and access to treatment. J Policy Anal Manage. 2015 Spring;34(2):328–53. X-125893237
3185 Chen B, Fan GG, Liu H, . Changes in anatomical and functional connectivity of Parkinson’s disease patients according to cognitive status. Eur J Radiol. 2015 Jul;84(7):1318–24. doi: 10.1016/j.ejrad.2015.04.014. X-125963506
3186 Chen CK, Shyur SD, Chu SH, . Pachydermodactyly: Three new cases in Taiwan. J Microbiol Immunol Infect. 2015 Jun;48(3):340–4. doi: 10.1016/j.jmii.2012.09.002. X-123218407
3187 Chen FC, Tsai CL. A light fingertip touch reduces postural sway in children with autism spectrum disorders. Gait Posture. 2015 Sep 25 doi: 10.1016/j.gaitpost.2015.09.012. X-3
3188 Chen JL, Sung C, Pi S. Vocational Rehabilitation Service Patterns and Outcomes for Individuals with Autism of Different Ages. J Autism Dev Disord. 2015 Sep;45(9):3015–29. doi: 10.1007/s10803-015-2465-y. X-125982310
3189 Chen L, Tai WC, Brar MS, . Tumor grafting induces changes of gut microbiota in athymic nude mice in the presence and absence of medicinal Gynostemma saponins. PLoS One. 2015;10(5):e0126807. doi: 10.1371/journal.pone.0126807. X-125992551
3190 Chen LS, Xu L, Dhar SU, . Autism spectrum disorders: a qualitative study of attitudes toward prenatal genetic testing and termination decisions of affected pregnancies. Clin Genet. 2015 Aug;88(2):122–8. doi: 10.1111/cge.12504. X-125251361
3191 Chhabra R, Ruozi B, Vilella A, . Application of Polymeric Nanoparticles for CNS Targeted Zinc Delivery In Vivo. CNS Neurol Disord Drug Targets. 2015;14(8):1041–53. X-126295815
3192 Chi OZ, Wu CC, Liu X, . Restoration of Normal Cerebral Oxygen Consumption with Rapamycin Treatment in a Rat Model of Autism-Tuberous Sclerosis. Neuromolecular Med. 2015 Sep;17(3):305–13. doi: 10.1007/s12017-015-8359-5. X-126048361
3193 Chiam JT, Dobson RJ, Kiddle SJ, . Are blood-based protein biomarkers for Alzheimer’s disease also involved in other brain disorders? A systematic review. J Alzheimers Dis. 2015;43(1):303–14. doi: 10.3233/jad-140816. X-125096613
3194 Chiang CH, Chu CL, Lee TC. Efficacy of caregiver-mediated joint engagement intervention for young children with autism spectrum disorders. Autism. 2015 Apr 20 doi: 10.1177/1362361315575725. X-1
3195 Chiang HL, Gau SS. Comorbid psychiatric conditions as mediators to predict later social adjustment in youths with autism spectrum disorder. J Child Psychol Psychiatry. 2015 Aug 6 doi: 10.1111/jcpp.12450. X-1
3196 Chikako F, Okada A, Akagi T, . Analysis of the synthetic-HTP drawing test about developmental disorders. Pediatr Int. 2015 Aug 13 doi: 10.1111/ped.12790. X-1
3197 Chita-Tegmark M, Arunachalam S, Nelson CA, . Eye-Tracking Measurements of Language Processing: Developmental Differences in Children at High Risk for ASD. J Autism Dev Disord. 2015 Oct;45(10):3327–38. doi: 10.1007/s10803-015-2495-5. X-126109246
3198 Chiu TA, Anagnostou E, Brian J, . Specificity of autonomic arousal to anxiety in children with autism spectrum disorder. Autism Res. 2015 Sep 21 doi: 10.1002/aur.1528. X-1
3199 Ch’ng C, Kwok W, Rogic S, . Meta-Analysis of Gene Expression in Autism Spectrum Disorder. Autism Res. 2015 Oct;8(5):593–608. doi: 10.1002/aur.1475. X-125720351
3200 Chowdhury M, Aman MG, Lecavalier L, . Factor structure and psychometric properties of the revised Home Situations Questionnaire for autism spectrum disorder: The Home Situations Questionnaire-Autism Spectrum Disorder. Autism. 2015 Jul 17 doi: 10.1177/1362361315593941. X-1
3201 Christon LM, Arnold CC, Myers BJ. Professionals’ reported provision and recommendation of psychosocial interventions for youth with autism spectrum disorder. Behav Ther. 2015 Jan;46(1):68–82. doi: 10.1016/j.beth.2014.02.002. X-125526836
3202 Clarke AR, Barry RJ, Indraratna A, . EEG activity in children with Asperger’s Syndrome. Clin Neurophysiol. 2015 Jun 15 doi: 10.1016/j.clinph.2015.05.015. X-1
3203 Clarke C. Autism Spectrum Disorder and Amplified Pain. Case Rep Psychiatry. 2015;2015:930874. doi: 10.1155/2015/930874. X-126064754
3204 Clarke TK, Lupton MK, Fernandez-Pujals AM, . Common polygenic risk for autism spectrum disorder (ASD) is associated with cognitive ability in the general population. Mol Psychiatry. 2015 Mar 10 doi: 10.1038/mp.2015.12. X-1
3205 Clausi S, Coricelli G, Pisotta I, . Cerebellar damage impairs the self-rating of regret feeling in a gambling task. Front Behav Neurosci. 2015;9:113. doi: 10.3389/fnbeh.2015.00113. X-125999829
3206 Cleary L, Brady N, Fitzgerald M, . Holistic processing of faces as measured by the Thatcher illusion is intact in autism spectrum disorders. Autism. 2015 May;19(4):451–8. doi: 10.1177/1362361314526005. X-124637429
3207 Cleland N, Lieblich S, Schalling M, . A 16-year-old girl with anti-NMDA-receptor encephalitis and family history of psychotic disorders. Acta Neuropsychiatr. 2015 Jun 1:1–5. doi: 10.1017/neu.2015.32. X-1
3208 Clowry GJ. An enhanced role and expanded developmental origins for gamma-aminobutyric acidergic interneurons in the human cerebral cortex. J Anat. 2015 Oct;227(4):384–93. doi: 10.1111/joa.12198. X-124839870
3209 Cochran DM, Sikoglu EM, Hodge SM, . Relationship among Glutamine, gamma-Aminobutyric Acid, and Social Cognition in Autism Spectrum Disorders. J Child Adolesc Psychopharmacol. 2015 May;25(4):314–22. doi: 10.1089/cap.2014.0112. X-125919578
3210 Cochran L, Moss J, Nelson L, . Contrasting age related changes in autism spectrum disorder phenomenology in Cornelia de Lange, Fragile X, and Cri du Chat syndromes: Results from a 2.5 year follow-up. Am J Med Genet C Semin Med Genet. 2015 Jun;169(2):188–97. doi: 10.1002/ajmg.c.31438. X-125989416
3211 Coeckelbergh M, Pop C, Simut R, . A Survey of Expectations About the Role of Robots in Robot-Assisted Therapy for Children with ASD: Ethical Acceptability, Trust, Sociability, Appearance, and Attachment. Sci Eng Ethics. 2015 Apr 17 doi: 10.1007/s11948-015-9649-x. X-1
3212 Coiro P, Padmashri R, Suresh A, . Impaired synaptic development in a maternal immune activation mouse model of neurodevelopmental disorders. Brain Behav Immun. 2015 Jul 26 doi: 10.1016/j.bbi.2015.07.022. X-1
3213 Coleman MB, Cherry RA, Moore TC, . Teaching Sight Words to Elementary Students With Intellectual Disability and Autism: A Comparison of Teacher-Directed Versus Computer-Assisted Simultaneous Prompting. Intellect Dev Disabil. 2015 Jun;53(3):196–210. doi: 10.1352/1934-9556-53.3.196. X-1, X-3, X-426107853
3214 Collyer K, Harrington I. Sensory regulation for inclusive classrooms. Asperger syndrome: Risk factors, cognitive-behavioral characteristics and management strategies.: Nova Biomedical Books, Hauppauge, NY; 2015:9–21.
3215 Conner KO, McKinnon SA, Ward CJ, . Peer education as a strategy for reducing internalized stigma among depressed older adults. Psychiatr Rehabil J. 2015 Jun;38(2):186–93. doi: 10.1037/prj0000109. X-125915057
3216 Constantino JN, Zhang Y, Holzhauer K, . Distribution and Within-Family Specificity of Quantitative Autistic Traits in Patients with Neurofibromatosis Type I. J Pediatr. 2015 Sep;167(3):621–6.e1. doi: 10.1016/j.jpeds.2015.04.075. X-126051969
3217 Conti E, Pannek K, Calderoni S, . High angular resolution diffusion imaging in a child with autism spectrum disorder and comparison with his unaffected identical twin. Funct Neurol. 2015 Oct 5:1–6. X-1
3218 Conti R. Compassionate Parenting as a Key to Satisfaction, Efficacy and Meaning Among Mothers of Children with Autism. J Autism Dev Disord. 2015 Jul;45(7):2008–18. doi: 10.1007/s10803-015-2360-6. X-125601216
3219 Cook R, Shah P, Gaule A, . Autism and Developmental Prosopagnosia: A Cross-Disorder Study. J Vis. 2015 Sep 1;15(12):1211. doi: 10.1167/15.12.1211. X-1
3220 Cooper M, Thapar A, Jones DK. ADHD severity is associated with white matter microstructure in the subgenual cingulum. Neuroimage Clin. 2015;7:653–60. doi: 10.1016/j.nicl.2015.02.012. X-125844319
3221 Cooper RA, Plaisted-Grant KC, Hannula DE, . Impaired recollection of visual scene details in adults with autism spectrum conditions. J Abnorm Psychol. 2015 Aug;124(3):565–75. doi: 10.1037/abn0000070. X-126120966
3222 Coorg R, Weisenberg JL. Successful Treatment of Electrographic Status Epilepticus Of Sleep With Felbamate in a Patient With SLC9A6 Mutation. Pediatr Neurol. 2015 Jul 22 doi: 10.1016/j.pediatrneurol.2015.07.007. X-1
3223 Corbett BA, Key AP, Qualls L, . Improvement in Social Competence Using a Randomized Trial of a Theatre Intervention for Children with Autism Spectrum Disorder. J Autism Dev Disord. 2015 Sep 29 doi: 10.1007/s10803-015-2600-9. X-1
3224 Corbett J, Melcher D. Evidence for global perceptual averaging in individuals with Autism Spectrum Disorder. J Vis. 2015 Sep 1;15(12):847. doi: 10.1167/15.12.847. X-1
3225 Corcoran J, Berry A, Hill S. The lived experience of US parents of children with autism spectrum disorders: A systematic review and meta-synthesis. J Intellect Disabil. 2015 Mar 27 doi: 10.1177/1744629515577876. X-1, X-2
3226 Cordier R, Brown N, Chen YW, . Piloting the use of experience sampling method to investigate the everyday social experiences of children with Asperger syndrome/high functioning autism. Dev Neurorehabil. 2015 Aug 24:1–8. doi: 10.3109/17518423.2014.915244. X-1
3227 Costales JL, Kolevzon A. Phelan-McDermid Syndrome and SHANK3: Implications for Treatment. Neurotherapeutics. 2015 Jul;12(3):620–30. doi: 10.1007/s13311-015-0352-z. X-125894671
3228 Costescu CA, Vanderborght B, David DO. Reversal Learning Task in Children with Autism Spectrum Disorder: A Robot-Based Approach. J Autism Dev Disord. 2015 Nov;45(11):3715–25. doi: 10.1007/s10803-014-2319-z. X-1, X-325479815
3229 Courchesne V, Meilleur AA, Poulin-Lord MP, . Autistic children at risk of being underestimated: school-based pilot study of a strength-informed assessment. Mol Autism. 2015;6:12. doi: 10.1186/s13229-015-0006-3. X-125774281
3230 Cox CR, Eaton S, Ekas NV, . Death concerns and psychological well-being in mothers of children with autism spectrum disorder. Res Dev Disabil. 2015 Oct–Nov;45–46:229–38. doi: 10.1016/j.ridd.2015.07.029. X-1
3231 Craig F, Lamanna AL, Margari F, . Overlap Between Autism Spectrum Disorders and Attention Deficit Hyperactivity Disorder: Searching for Distinctive/Common Clinical Features. Autism Res. 2015 Jun;8(3):328–37. doi: 10.1002/aur.1449. X-125604000
3232 Cranwell M, Riby D, Le Couteur A, . Dissociation of chromatic discrimination ability in developmental disorders: Autism Spectrum Disorder and Williams Syndrome. J Vis. 2015 Sep 1;15(12):645. doi: 10.1167/15.12.645. X-1
3233 Crawford JD, Chandley MJ, Szebeni K, . Elevated GFAP Protein in Anterior Cingulate Cortical White Matter in Males With Autism Spectrum Disorder. Autism Res. 2015 Apr 6 doi: 10.1002/aur.1480. X-1
3234 Croen LA, Zerbo O, Qian Y, . The health status of adults on the autism spectrum. Autism. 2015 Oct;19(7):814–23. doi: 10.1177/1362361315577517. X-125911091
3235 Cromarty RA, Elder GJ, Graziadio S, . Neurophysiological biomarkers for Lewy body dementias. Clin Neurophysiol. 2015 Jun 27 doi: 10.1016/j.clinph.2015.06.020. X-1
3236 Crook JM, Wallace G, Tomaskovic-Crook E. The potential of induced pluripotent stem cells in models of neurological disorders: implications on future therapy. Expert Rev Neurother. 2015 Mar;15(3):295–304. doi: 10.1586/14737175.2015.1013096. X-125664599
3237 Crutchfield SA, Mason RA, Chambers A, . Use of a Self-monitoring Application to Reduce Stereotypic Behavior in Adolescents with Autism: A Preliminary Investigation of I-Connect. J Autism Dev Disord. 2015 May;45(5):1146–55. doi: 10.1007/s10803-014-2272-x. X-1, X-3, X-425326255
3238 Curran EA, Dalman C, Kearney PM, . Association Between Obstetric Mode of Delivery and Autism Spectrum Disorder: A Population-Based Sibling Design Study. JAMA Psychiatry. 2015 Sep 1;72(9):935–42. doi: 10.1001/jamapsychiatry.2015.0846. X-126107922
3239 Curran EA, O’Neill SM, Cryan JF, . Research review: Birth by caesarean section and development of autism spectrum disorder and attention-deficit/hyperactivity disorder: a systematic review and meta-analysis. J Child Psychol Psychiatry. 2015 May;56(5):500–8. doi: 10.1111/jcpp.12351. X-125348074
3240 Curtin C, Hubbard K, Anderson SE, . Food Selectivity, Mealtime Behavior Problems, Spousal Stress, and Family Food Choices in Children with and without Autism Spectrum Disorder. J Autism Dev Disord. 2015 Oct;45(10):3308–15. doi: 10.1007/s10803-015-2490-x. X-126070276
3241 Curtin C, Humphrey K, Vronsky K, . Expanding Horizons: A Pilot Mentoring Program Linking College/Graduate Students and Teens With ASD. Clin Pediatr (Phila). 2015 May 27 doi: 10.1177/0009922815588821. X-1
3242 Dababnah S, Bulson K. “On the Sidelines”: Access to Autism-Related Services in the West Bank. J Autism Dev Disord. 2015 Jul 29 doi: 10.1007/s10803-015-2538-y. X-1
3243 Dababnah S, Parish SL. A Comprehensive Literature Review of Randomized Controlled Trials for Parents of Young Children with Autism Spectrum Disorder. J Evid Inf Soc Work. 2015 Jul 15:1–16. doi: 10.1080/23761407.2015.1052909. X-2
3244 Dababnah S, Parish SL. Feasibility of an empirically based program for parents of preschoolers with autism spectrum disorder. Autism. 2015 Feb 25 doi: 10.1177/1362361314568900. X-1, X-3
3245 D’Agostino G, Cristiano C, Lyons DJ, . Peroxisome proliferator-activated receptor alpha plays a crucial role in behavioral repetition and cognitive flexibility in mice. Mol Metab. 2015 Jul;4(7):528–36. doi: 10.1016/j.molmet.2015.04.005. X-126137440
3246 Daimon CM, Jasien JM, Wood WH, 3rd, . Hippocampal Transcriptomic and Proteomic Alterations in the BTBR Mouse Model of Autism Spectrum Disorder. Front Physiol. 2015;6:324. doi: 10.3389/fphys.2015.00324. X-126635614
3247 Daluwatte C, Miles JH, Sun J, . Association between pupillary light reflex and sensory behaviors in children with autism spectrum disorders. Research in Developmental Disabilities. 2015 2015-12-09;37:209–15. doi: http://dx.doi.org/10.1016/j.ridd.2014.11.019; 2015-05377-025. X-125528080
3248 Danzer E, Gerdes M, D’Agostino JA, . Patient characteristics are important determinants of neurodevelopmental outcome during infancy in giant omphalocele. Early Hum Dev. 2015 Mar;91(3):187–93. doi: 10.1016/j.earlhumdev.2014.12.009. X-125676186
3249 Das DK, Tapias V, D’Aiuto L, . Genetic and morphological features of human iPSC-derived neurons with chromosome 15q11.2 (BP1–BP2) deletions. Mol Neuropsychiatry. 2015 Jul;1(2):116–23. doi: 10.1159/000430916. X-126528485
3250 David M, Billette de Villemeur A, Devillard F, . [Schooling and care of mild intellectual disability children]. Arch Pediatr. 2015 Mar;22(3):223–34. doi: 10.1016/j.arcped.2014.12.006. X-125656456
3251 Davidovitch M, Levit-Binnun N, Golan D, . Late diagnosis of autism spectrum disorder after initial negative assessment by a multidisciplinary team. J Dev Behav Pediatr. 2015 May;36(4):227–34. doi: 10.1097/dbp.0000000000000133. X-125651066
3252 Davidson C, O’Hare A, Mactaggart F, . Social relationship difficulties in autism and reactive attachment disorder: Improving diagnostic validity through structured assessment. Res Dev Disabil. 2015 May;40:63–72. doi: 10.1016/j.ridd.2015.01.007. X-125754456
3253 Davis PE, Peters JM, Krueger DA, . Tuberous Sclerosis: A New Frontier in Targeted Treatment of Autism. Neurotherapeutics. 2015 Jul;12(3):572–83. doi: 10.1007/s13311-015-0359-5. X-125986747
3254 Davis T, Clifton D, Papadopoulos C. Identifying autism early: The Toddlers at Risk of Autism Clinic model. J Paediatr Child Health. 2015 Jul;51(7):699–703. doi: 10.1111/jpc.12832. X-125623060
3255 De Angelis M, Francavilla R, Piccolo M, . Autism spectrum disorders and intestinal microbiota. Gut Microbes. 2015;6(3):207–13. doi: 10.1080/19490976.2015.1035855. X-125835343
3256 de Araujo MF, Matsumoto J, Ono T, . An animal model of disengagement: Temporary inactivation of the superior colliculus impairs attention disengagement in rats. Behav Brain Res. 2015 Oct 15;293:34–40. doi: 10.1016/j.bbr.2015.07.031. X-126196954
3257 de Bruin EI, Blom R, Smit FM, . MYmind: Mindfulness training for Youngsters with autism spectrum disorders and their parents. Autism. 2015 Nov;19(8):906–14. doi: 10.1177/1362361314553279. X-1, X-325348866
3258 de Esch CE, van den Berg WE, Buijsen RA, . Fragile X mice have robust mGluR5-dependent alterations of social behaviour in the Automated Tube Test. Neurobiol Dis. 2015 Mar;75:31–9. doi: 10.1016/j.nbd.2014.12.021. X-125562659
3259 De Filippis B, Valenti D, de Bari L, . Mitochondrial free radical overproduction due to respiratory chain impairment in the brain of a mouse model of Rett syndrome: protective effect of CNF1. Free Radic Biol Med. 2015 Jun;83:167–77. doi: 10.1016/j.freeradbiomed.2015.02.014. X-125708779
3260 De Giacomo A, Craig F, Cristella A, . Can PEP-3 Provide a Cognitive Profile in Children with ASD? A Comparison Between the Developmental Ages of PEP-3 and IQ of Leiter-R. J Appl Res Intellect Disabil. 2015 Oct 6 doi: 10.1111/jar.12216. X-1
3261 De Giacomo A, De Giambattista C, Balducci R, . [SCQ as a tool for screening ASD comorbidities with ADHD]. Riv Psichiatr. 2015 Jan–Feb;50(1):34–7. doi: 10.1708/1794.19534. X-125805353
3262 de la Hoz AB, Maortua H, Garcia-Rives A, . 3p14 De Novo Interstitial Microdeletion in a Patient with Intellectual Disability and Autistic Features with Language Impairment: A Comparison with Similar Cases. Case Rep Genet. 2015;2015:876348. doi: 10.1155/2015/876348. X-126075115
3263 de Lissa P, Sorensen S, Badcock N, . Measuring the face-sensitive N170 with a gaming EEG system: A validation study. J Neurosci Methods. 2015 Sep 30;253:47–54. doi: 10.1016/j.jneumeth.2015.05.025. X-126057115
3264 de Marchena AB, Eigsti IM, Yerys BE. Brief Report: Generalization Weaknesses in Verbally Fluent Children and Adolescents with Autism Spectrum Disorder. J Autism Dev Disord. 2015 Oct;45(10):3370–6. doi: 10.1007/s10803-015-2478-6. X-126031922
3265 de Schipper E, Lundequist A, Coghill D, . Ability and Disability in Autism Spectrum Disorder: A Systematic Literature Review Employing the International Classification of Functioning, Disability and Health-Children and Youth Version. Autism Res. 2015 Mar 28 doi: 10.1002/aur.1485. X-1
3266 de Vaan G, Vervloed M, Peters-Scheffer NC, . Behavioural assessment of autism spectrum disorders in people with multiple disabilities. J Intellect Disabil Res. 2015 Jun 8 doi: 10.1111/jir.12206. X-1
3267 de Vinck-Baroody O, Shui A, Macklin EA, . Overweight and Obesity in a Sample of Children With Autism Spectrum Disorder. Acad Pediatr. 2015 Jul–Aug;15(4):396–404. doi: 10.1016/j.acap.2015.03.008. X-125937610
3268 de Vries M, Geurts H. Influence of Autism Traits and Executive Functioning on Quality of Life in Children with an Autism Spectrum Disorder. J Autism Dev Disord. 2015 Sep;45(9):2734–43. doi: 10.1007/s10803-015-2438-1. X-125835211
3269 de Vries M, Prins PJ, Schmand BA, . Working memory and cognitive flexibility-training for children with an autism spectrum disorder: a randomized controlled trial. J Child Psychol Psychiatry. 2015 May;56(5):566–76. doi: 10.1111/jcpp.12324. X-125256627
3270 Dekker LP, van der Vegt EJ, Visser K, . Improving psychosexual knowledge in adolescents with autism spectrum disorder: pilot of the tackling teenage training program. J Autism Dev Disord. 2015 Jun;45(6):1532–40. doi: 10.1007/s10803-014-2301-9. X-125399394
3271 Dekkers LM, Groot NA, Diaz Mosquera EN, . Prevalence of Autism Spectrum Disorders in Ecuador: A Pilot Study in Quito. J Autism Dev Disord. 2015 Aug 30 doi: 10.1007/s10803-015-2559-6. X-1
3272 Dell’Osso L, Dalle Luche R, Cerliani C, . Unexpected subthreshold autism spectrum in a 25-year-old male stalker hospitalized for delusional disorder: a case report. Compr Psychiatry. 2015 Aug;61:10–4. doi: 10.1016/j.comppsych.2015.04.003. X-126031384
3273 Delude CM. Deep phenotyping: The details of disease. Nature. 2015 Nov 5;527(7576):S14–5. doi: 10.1038/527S14a. X-126536218
3274 Demopoulos C, Arroyo MS, Dunn W, . Individuals with agenesis of the corpus callosum show sensory processing differences as measured by the sensory profile. Neuropsychology. 2015 Sep;29(5):751–8. doi: 10.1037/neu0000165. X-125528608
3275 Demopoulos C, Brandes-Aitken AN, Desai SS, . Shared and Divergent Auditory and Tactile Processing in Children with Autism and Children with Sensory Processing Dysfunction Relative to Typically Developing Peers. J Int Neuropsychol Soc. 2015 Jul;21(6):444–54. doi: 10.1017/s1355617715000387. X-126145730
3276 Demopoulos C, Hopkins J, Kopald BE, . Deficits in Auditory Processing Contribute to Impairments in Vocal Affect Recognition in Autism Spectrum Disorders: A MEG Study. Neuropsychology. 2015 May 25 doi: 10.1037/neu0000209. X-1
3277 Demopoulos C, Lewine JD. Audiometric Profiles in Autism Spectrum Disorders: Does Subclinical Hearing Loss Impact Communication? Autism Res. 2015 May 11 doi: 10.1002/aur.1495. X-1
3278 Deoni SC, Zinkstok JR, Daly E, . White-matter relaxation time and myelin water fraction differences in young adults with autism. Psychol Med. 2015 Mar;45(4):795–805. doi: 10.1017/s0033291714001858. X-125111948
3279 DeQuinzio JA, Taylor BA. Teaching children with autism to discriminate the reinforced and nonreinforced responses of others: implications for observational learning. J Appl Behav Anal. 2015 Spring;48(1):38–51. doi: 10.1002/jaba.192. X-3, X-425689037
3280 Derakhshan N. Vagal Nerve Stimulation for the Treatment of Autism. Ment Illn. 2015 Feb 24;7(1):5788. doi: 10.4081/mi.2015.5788. X-1, X-2, X-326266025
3281 Derosa NM, Fisher WW, Steege MW. An evaluation of time in establishing operation on the effectiveness of functional communication training. J Appl Behav Anal. 2015 Spring;48(1):115–30. doi: 10.1002/jaba.180. X-125420612
3282 Desachy G, Croen LA, Torres AR, . Increased female autosomal burden of rare copy number variants in human populations and in autism families. Mol Psychiatry. 2015 Feb;20(2):170–5. doi: 10.1038/mp.2014.179. X-125582617
3283 DeThorne L, Aparicio Betancourt M, Karahalios K, . Visualizing Syllables: Real-Time Computerized Feedback Within a Speech-Language Intervention. J Autism Dev Disord. 2015 Nov;45(11):3756–63. doi: 10.1007/s10803-014-2274-8. X-125344794
3284 Devriese J, Dhar M, Walleghem D, . [Hallucinations and obsessive behaviour in an infant with autism spectrum disorder: diagnostic problems]. Tijdschr Psychiatr. 2015;57(8):608–12. X-126402898
3285 Dewinter J, Vermeiren R, Vanwesenbeeck I, . Parental Awareness of Sexual Experience in Adolescent Boys With Autism Spectrum Disorder. J Autism Dev Disord. 2015 Oct 19 doi: 10.1007/s10803-015-2622-3. X-1
3286 Di Marino D, D’Annessa I, Tancredi H, . A unique binding mode of the eukaryotic translation initiation factor 4E for guiding the design of novel peptide inhibitors. Protein Sci. 2015 Sep;24(9):1370–82. doi: 10.1002/pro.2708. X-126013047
3287 Di Renzo M, Bianchi Di Castelbianco F, Petrillo M, . ASSESSMENT OF A LONG-TERM DEVELOPMENTAL RELATIONSHIP-BASED APPROACH IN CHILDREN WITH AUTISM SPECTRUM DISORDER. Psychol Rep. 2015 Aug;117(1):26–49. doi: 10.2466/15.10.PR0.117c15z8. X-326270989
3288 Di Venanzio C, Marinelli M, Tonnetti A, . Comparison between small radiation therapy electron beams collimated by Cerrobend and tubular applicators. J Appl Clin Med Phys. 2015;16(1):5186. doi: 10.1120/jacmp.v16i1.5186. X-125679175
3289 Di Venanzio C, Marinelli M, Tonnetti A, . Characterization of a microDiamond detector in high-dose-per-pulse electron beams for intra operative radiation therapy. Phys Med.. 2015 Jul 6 doi: 10.1016/j.ejmp.2015.06.008. X-1
3290 Dickerson AS, Rahbar MH, Han I, . Autism spectrum disorder prevalence and proximity to industrial facilities releasing arsenic, lead or mercury. Sci Total Environ. 2015 Dec 1;536:245–51. doi: 10.1016/j.scitotenv.2015.07.024. X-126218563
3291 Dickerson Mayes S, Calhoun SL, Baweja R, . Suicide ideation and attempts in children with psychiatric disorders and typical development. Crisis. 2015;36(1):55–60. doi: 10.1027/0227-5910/a000284. X-125410255
3292 Diehl JJ, Friedberg C, Paul R, . The use of prosody during syntactic processing in children and adolescents with autism spectrum disorders. Dev Psychopathol. 2015 Aug;27(3):867–84. doi: 10.1017/s0954579414000741. X-125156911
3293 Dillen C, Steyaert J, Op de Beeck HP, . Visual processing in adolescents with autism spectrum disorder: evidence from embedded figures and configural superiority tests. J Autism Dev Disord. 2015 May;45(5):1281–90. doi: 10.1007/s10803-014-2288-2. X-125342435
3294 Dillenburger K, McKerr L, Jordan JA, . Creating an Inclusive Society… How Close are We in Relation to Autism Spectrum Disorder? A General Population Survey. J Appl Res Intellect Disabil. 2015 Jul;28(4):330–40. doi: 10.1111/jar.12144. X-125808648
3295 Dimitriou D, Leonard HC, Karmiloff-Smith A, . Atypical development of configural face recognition in children with autism, Down syndrome and Williams syndrome. J Intellect Disabil Res. 2015 May;59(5):422–38. doi: 10.1111/jir.12141. X-125059077
3296 Dinecola CM, Lemieux CM. Practice with persons with autism spectrum disorders: predictors of self-efficacy among social work students. J Soc Work Disabil Rehabil. 2015;14(1):23–40. doi: 10.1080/1536710x.2015.989559. X-125584441
3297 Ditzian K, Wilder DA, King A, . An evaluation of the Performance Diagnostic Checklist-Human Services to assess an employee performance problem in a center-based autism treatment facility. J Appl Behav Anal. 2015 Spring;48(1):199–203. doi: 10.1002/jaba.171. X-125311712
3298 Divan G, Hamdani SU, Vajartkar V, . Adapting an evidence-based intervention for autism spectrum disorder for scaling up in resource-constrained settings: the development of the PASS intervention in South Asia. Glob Health Action. 2015;8:27278. doi: 10.3402/gha.v8.27278. X-1, X-2
3299 Doll CA, Broadie K. Activity-dependent FMRP requirements in development of the neural circuitry of learning and memory. Development. 2015 Apr 1;142(7):1346–56. doi: 10.1242/dev.117127. X-125804740
3300 Dominick K, Wink LK, McDougle CJ, . A Retrospective Naturalistic Study of Ziprasidone for Irritability in Youth with Autism Spectrum Disorder. J Child Adolesc Psychopharmacol. 2015 Jun;25(5):397–401. doi: 10.1089/cap.2014.0111. X-326091194
3301 Dong L, Yan H, Huang X, . A2BP1 gene polymorphisms association with olanzapine-induced weight gain. Pharmacol Res. 2015 Sep;99:155–61. doi: 10.1016/j.phrs.2015.06.003. X-126092620
3302 Donkers FC, Schipul SE, Baranek GT, . Attenuated auditory event-related potentials and associations with atypical sensory response patterns in children with autism. J Autism Dev Disord. 2015 Feb;45(2):506–23. doi: 10.1007/s10803-013-1948-y. X-124072639
3303 Donovan MD, O’Brien FE, Boylan GB, . The effect of organic anion transporter 3 inhibitor probenecid on bumetanide levels in the brain: an integrated in vivo microdialysis study in the rat. J Pharm Pharmacol. 2015 Apr;67(4):501–10. doi: 10.1111/jphp.12341. X-125490899
3304 Doshi-Velez F, Avillach P, Palmer N, . Prevalence of Inflammatory Bowel Disease Among Patients with Autism Spectrum Disorders. Inflamm Bowel Dis. 2015 Oct;21(10):2281–8. doi: 10.1097/mib.0000000000000502. X-126218138
3305 Dougherty CC, Evans DW, Myers SM, . A Comparison of Structural Brain Imaging Findings in Autism Spectrum Disorder and Attention-Deficit Hyperactivity Disorder. Neuropsychol Rev. 2015 Oct 19 doi: 10.1007/s11065-015-9300-2. X-1
3306 Douglas NF, Campbell WN, Hinckley JJ. Implementation Science: Buzzword or Game Changer? J Speech Lang Hear Res. 2015 Oct 16 doi: 10.1044/2015_jslhr-l-15-0302. X-1
3307 Downs J, Hotopf M, Ford T, . Clinical predictors of antipsychotic use in children and adolescents with autism spectrum disorders: a historical open cohort study using electronic health records. Eur Child Adolesc Psychiatry. 2015 Oct 15 doi: 10.1007/s00787-015-0780-7. X-1
3308 Doyen C, Contejean Y, Risler V, . [Cognitive remediation therapy for children: literature data and clinical application in a child and adolescent psychiatry department]. Arch Pediatr. 2015 Apr;22(4):418–26. doi: 10.1016/j.arcped.2015.01.012. X-1, X-3, X-425736104
3309 Dreyer Gillette ML, Borner KB, Nadler CB, . Prevalence and Health Correlates of Overweight and Obesity in Children with Autism Spectrum Disorder. J Dev Behav Pediatr. 2015 Sep;36(7):489–96. doi: 10.1097/dbp.0000000000000198. X-126166285
3310 D’Souza D, Booth R, Connolly M, . Rethinking the concepts of ‘local or global processors’: evidence from Williams syndrome, Down syndrome, and Autism Spectrum Disorders. Dev Sci. 2015 May 25 doi: 10.1111/desc.12312. X-1
3311 Du L, Shan L, Wang B, . A Pilot Study on the Combination of Applied Behavior Analysis and Bumetanide Treatment for Children with Autism. J Child Adolesc Psychopharmacol. 2015 Sep;25(7):585–8. doi: 10.1089/cap.2015.0045.26258842
3312 Du RY, Yiu CK, King NM, . Oral health among preschool children with autism spectrum disorders: A case-control study. Autism. 2015 Aug;19(6):746–51. doi: 10.1177/1362361314553439. X-125432504
3313 Duan G, Chen J, Zhang W, . Physical maltreatment of children with autism in Henan province in China: A cross-sectional study. Child Abuse Negl. 2015 Oct;48:140–7. doi: 10.1016/j.chiabu.2015.03.018. X-125957752
3314 Dubin AH, Lieberman-Betz R, Michele Lease A. Investigation of Individual Factors Associated with Anxiety in Youth with Autism Spectrum Disorders. J Autism Dev Disord. 2015 Sep;45(9):2947–60. doi: 10.1007/s10803-015-2458-x. X-125917383
3315 Ducharme S, Price BH, Larvie M, . Clinical Approach to the Differential Diagnosis Between Behavioral Variant Frontotemporal Dementia and Primary Psychiatric Disorders. Am J Psychiatry. 2015 Sep 1;172(9):827–37. doi: 10.1176/appi.ajp.2015.14101248. X-126324301
3316 Dudova I, Kocourkova J, Koutek J. Early-onset anorexia nervosa in girls with Asperger syndrome. Neuropsychiatr Dis Treat. 2015;11:1639–43. doi: 10.2147/ndt.s83831. X-126170676
3317 Duerden EG, Taylor MJ, Lee M, . Decreased sensitivity to thermal stimuli in adolescents with autism spectrum disorder: relation to symptomatology and cognitive ability. J Pain. 2015 May;16(5):463–71. doi: 10.1016/j.jpain.2015.02.001. X-125704841
3318 Duffney LJ, Zhong P, Wei J, . Autism-like Deficits in Shank3-Deficient Mice Are Rescued by Targeting Actin Regulators. Cell Rep. 2015 Jun 9;11(9):1400–13. doi: 10.1016/j.celrep.2015.04.064. X-126027926
3319 Duncan AW, Bishop SL. Understanding the gap between cognitive abilities and daily living skills in adolescents with autism spectrum disorders with average intelligence. Autism. 2015 Jan;19(1):64–72. doi: 10.1177/1362361313510068. X-124275020
3320 Dunleavy L. Evaluation of a continuing education course for occupational therapy practitioners on the use of applied behavior analysis. Occup Ther Health Care. 2015 Jan;29(1):39–53. doi: 10.3109/07380577.2014.950784. X-125180710
3321 Dupuis DL, Lerman DC, Tsami L, . Reduction of aggression evoked by sounds using noncontingent reinforcement and time-out. J Appl Behav Anal. 2015 Sep;48(3):669–74. doi: 10.1002/jaba.220. X-3, X-426118940
3322 Durrleman S, Hippolyte L, Zufferey S, . Complex syntax in autism spectrum disorders: a study of relative clauses. Int J Lang Commun Disord. 2015 Mar–Apr;50(2):260–7. doi: 10.1111/1460-6984.12130. X-125244532
3323 D’Urso G, Bruzzese D, Ferrucci R, . Transcranial direct current stimulation for hyperactivity and noncompliance in autistic disorder. World J Biol Psychiatry. 2015;16(5):361–6. doi: 10.3109/15622975.2015.1014411. X-3, X-425800799
3324 Dutheil F, Chambres P, Hufnagel C, . ‘Do Well B.’: Design Of WELL Being monitoring systems. A study protocol for the application in autism. BMJ Open. 2015;5(2):e007716. doi: 10.1136/bmjopen-2015-007716. X-1
3325 Duvekot J, van der Ende J, Verhulst FC, . The Screening Accuracy of the Parent and Teacher-Reported Social Responsiveness Scale (SRS): Comparison with the 3Di and ADOS. J Autism Dev Disord. 2015 Jun;45(6):1658–72. doi: 10.1007/s10803-014-2323-3. X-125428292
3326 Ebrahimi-Fakhari D, Sahin M. Autism and the synapse: emerging mechanisms and mechanism-based therapies. Curr Opin Neurol. 2015 Apr;28(2):91–102. doi: 10.1097/wco.0000000000000186. X-125695134
3327 Ebrahimzadeh MA, Safdari Y, Khalili M. Antioxidant Activity of Different Fractions of Methanolic Extract of the Golden Chanterelle Mushroom Cantharellus cibarius (Higher Basidiomycetes) from Iran. Int J Med Mushrooms. 2015;17(6):557–65. X-126349513
3328 Edgar JC, Khan SY, Blaskey L, . Neuromagnetic oscillations predict evoked-response latency delays and core language deficits in autism spectrum disorders. J Autism Dev Disord. 2015 Feb;45(2):395–405. doi: 10.1007/s10803-013-1904-x. X-123963591
3329 Edgin JO, Tooley U, Demara B, . Sleep Disturbance and Expressive Language Development in Preschool-Age Children With Down Syndrome. Child Dev. 2015 Oct 5 doi: 10.1111/cdev.12443. X-1
3330 Egawa J, Watanabe Y, Wang C, . Novel rare missense variations and risk of autism spectrum disorder: whole-exome sequencing in two families with affected siblings and a two-stage follow-up study in a Japanese population. PLoS One. 2015;10(3):e0119413. doi: 10.1371/journal.pone.0119413. X-125806950
3331 Eisenberg IW, Wallace GL, Kenworthy L, . Insistence on sameness relates to increased covariance of gray matter structure in autism spectrum disorder. Mol Autism. 2015;6:54. doi: 10.1186/s13229-015-0047-7. X-126435832
3332 El Zein F, Solis M, Lang R, . Embedding perseverative interest of a child with autism in text may result in improved reading comprehension: A pilot study. Dev Neurorehabil. 2015 Aug 24:1–5. doi: 10.3109/17518423.2014.915893. X-1, X-3, X-4
3333 El-Ansary A, Bhat RS, Al-Daihan S, . The neurotoxic effects of ampicillin-associated gut bacterial imbalances compared to those of orally administered propionic acid in the etiology of persistent autistic features in rat pups: effects of various dietary regimens. Gut Pathog. 2015;7:7. doi: 10.1186/s13099-015-0054-4. X-125852770
3334 Ellis Weismer S, Kover ST. Preschool language variation, growth, and predictors in children on the autism spectrum. J Child Psychol Psychiatry. 2015 Mar 10 doi: 10.1111/jcpp.12406. X-1
3335 Elrod MG, Hood BS. Sleep differences among children with autism spectrum disorders and typically developing peers: a meta-analysis. J Dev Behav Pediatr. 2015 Apr;36(3):166–77. doi: 10.1097/dbp.0000000000000140. X-125741949
3336 Emily G, Grace I. Family quality of life and ASD: the role of child adaptive functioning and behavior problems. Autism Res. 2015 Apr;8(2):199–213. doi: 10.1002/aur.1442. X-125641930
3337 Endreffy I, Bjorklund G, Dicso F, . Acid glycosaminoglycan (aGAG) excretion is increased in children with autism spectrum disorder, and it can be controlled by diet. Metab Brain Dis. 2015 Oct 14 doi: 10.1007/s11011-015-9745-2. X-3
3338 Engelhardt CR, Mazurek MO, Hilgard J, . Effects of Violent-Video-Game Exposure on Aggressive Behavior, Aggressive-Thought Accessibility, and Aggressive Affect Among Adults With and Without Autism Spectrum Disorder. Psychol Sci. 2015 Aug;26(8):1187–200. doi: 10.1177/0956797615583038. X-126113064
3339 English MC, Maybery MT, Visser TA. Individuals with Autistic-Like Traits Show Reduced Lateralization on a Greyscales Task. J Autism Dev Disord. 2015 Oct;45(10):3390–5. doi: 10.1007/s10803-015-2493-7. X-126060048
3340 Epitropakis C, DiPietro EA. Medication compliance protocol for pediatric patients with severe intellectual and behavioral disabilities. J Pediatr Nurs. 2015 Mar–Apr;30(2):329–32. doi: 10.1016/j.pedn.2014.08.006. X-125193686
3341 Erbetta A, Bulgheroni S, Contarino VE, . Low-Functioning Autism and Nonsyndromic Intellectual Disability: Magnetic Resonance Imaging (MRI) Findings. J Child Neurol. 2015 Oct;30(12):1658–63. doi: 10.1177/0883073815578523. X-125895913
3342 Erviti M, Semal C, Wright BA, . A late-emerging auditory deficit in autism. Neuropsychology. 2015 May;29(3):454–62. doi: 10.1037/neu0000162. X-125495831
3343 Eryigit-Madzwamuse S, Strauss V, Baumann N, . Personality of adults who were born very preterm. Arch Dis Child Fetal Neonatal Ed. 2015 Nov;100(6):F524–9. doi: 10.1136/archdischild-2014-308007. X-126215406
3344 Esan F, Chester V, Gunaratna IJ, . The clinical, forensic and treatment outcome factors of patients with autism spectrum disorder treated in a forensic intellectual disability service. J Appl Res Intellect Disabil. 2015 May;28(3):193–200. doi: 10.1111/jar.12121. X-125379816
3345 Eshraghi AA, Nazarian R, Telischi FF, . Cochlear Implantation in Children With Autism Spectrum Disorder. Otol Neurotol. 2015 Sep;36(8):e121–8. doi: 10.1097/mao.0000000000000757. X-1, X-325899551
3346 Esler AN, Bal VH, Guthrie W, . The Autism Diagnostic Observation Schedule, Toddler Module: Standardized Severity Scores. J Autism Dev Disord. 2015 Sep;45(9):2704–20. doi: 10.1007/s10803-015-2432-7. X-125832801
3347 Esposito G, Setoh P, Yoshida S, . The calming effect of maternal carrying in different mammalian species. Front Psychol. 2015;6:445. doi: 10.3389/fpsyg.2015.00445. X-125932017
3348 Esposito G, Valenzi S, Islam T, . Three physiological responses in fathers and non-fathers’ to vocalizations of typically developing infants and infants with Autism Spectrum Disorder. Res Dev Disabil. 2015 Aug–Sep;43–44:43–50. doi: 10.1016/j.ridd.2015.06.007. X-1
3349 Estes A, Munson J, Rogers SJ, . Long-Term Outcomes of Early Intervention in 6-Year-Old Children With Autism Spectrum Disorder. J Am Acad Child Adolesc Psychiatry. 2015 Jul;54(7):580–7. doi: 10.1016/j.jaac.2015.04.005. X-1, X-326088663
3350 Estes A, Zwaigenbaum L, Gu H, . Behavioral, cognitive, and adaptive development in infants with autism spectrum disorder in the first 2 years of life. J Neurodev Disord. 2015;7(1):24. doi: 10.1186/s11689-015-9117-6. X-126203305
3351 Evers C, Mitter D, Strobl-Wildemann G, . Duplication Xp11.22-p14 in females: does X-inactivation help in assessing their significance? Am J Med Genet A. 2015 Mar;167a(3):553–62. doi: 10.1002/ajmg.a.36897. X-125691408
3352 Eversole M, Collins DM, Karmarkar A, . Leisure Activity Enjoyment of Children with Autism Spectrum Disorders. J Autism Dev Disord. 2015 Jul 26 doi: 10.1007/s10803-015-2529-z. X-1
3353 Ewbank M, Pell P, Powell T, . Reduced repetition suppression to faces in the fusiform face area of adults with autism spectrum conditions. J Vis. 2015 Sep 1;15(12):1210. doi: 10.1167/15.12.1210. X-1
3354 Faber S, Zinn GM, Boggess A, . A cleanroom sleeping environment’s impact on markers of oxidative stress, immune dysregulation, and behavior in children with autism spectrum disorders. BMC Complement Altern Med. 2015;15:71. doi: 10.1186/s12906-015-0564-0. X-125887094
3355 Fadini CC, Lamonica DA, Fett-Conte AC, . Influence of sleep disorders on the behavior of individuals with autism spectrum disorder. Front Hum Neurosci. 2015;9:347. doi: 10.3389/fnhum.2015.00347. X-126150777
3356 Faedda GL, Wachtel LE, Higgins AM, . Catatonia in an adolescent with velo-cardio-facial syndrome. Am J Med Genet A. 2015 Sep;167(9):2150–3. doi: 10.1002/ajmg.a.37087. X-1
3357 Fahmie TA, Iwata BA, Jann KE. Comparison of edible and leisure reinforcers. J Appl Behav Anal. 2015 Summer;48(2):331–43. doi: 10.1002/jaba.200. X-1, X-325891170
3358 Fairthorne J, de Klerk N, Leonard H. Brief Report: Burden of Care in Mothers of Children with Autism Spectrum Disorder or Intellectual Disability. J Autism Dev Disord. 2015 Oct 19 doi: 10.1007/s10803-015-2629-9. X-1
3359 Fairthorne J, Jacoby P, Bourke J, . Onset of maternal psychiatric disorders after the birth of a child with autism spectrum disorder: A retrospective cohort study. Autism. 2015 Feb 4 doi: 10.1177/1362361314566048. X-1
3360 Fakroon S, Arheiam A, Omar S. Dental caries experience and periodontal treatment needs of children with autistic spectrum disorder. Eur Arch Paediatr Dent. 2015 Apr;16(2):205–9. doi: 10.1007/s40368-014-0156-6. X-125385711
3361 Falck-Ytter T, Thorup E, Bolte S. Brief report: Lack of processing bias for the objects other people attend to in 3-year-olds with autism. J Autism Dev Disord. 2015 Jun;45(6):1897–904. doi: 10.1007/s10803-014-2278-4. X-125331324
3362 Falco MD, Masala S, Stefanini M, . Patient skin dose measurements using a cable free system MOSFETs based in fluoroscopically guided percutaneous vertebroplasty, percutaneous disc decompression, radiofrequency medial branch neurolysis, and endovascular critical limb ischemia. J Appl Clin Med Phys. 2015;16(1):5020. doi: 10.1120/jacmp.v16i1.5020. X-125679159
3363 Falcomata TS, Muething CS, Roberts GJ, . Further evaluation of latency-based brief functional analysis methods: An evaluation of treatment utility. Dev Neurorehabil. 2015 Aug 24:1–7. doi: 10.3109/17518423.2014.910281. X-1, X-3, X-4
3364 Falkmer M, Black M, Tang J, . Local visual perception bias in children with high-functioning autism spectrum disorders; do we have the whole picture? Dev Neurorehabil. 2015 Aug 24:1–6. doi: 10.3109/17518423.2014.928387. X-1, X-2
3365 Falkmer M, Oehlers K, Granlund M, . Can you see it too? Observed and self-rated participation in mainstream schools in students with and without autism spectrum disorders. Dev Neurorehabil. 2015 Aug 24:1–10. doi: 10.3109/17518423.2013.850751. X-1
3366 Farajollahi AR, Bouzarjomehri F, Kiani M. Comparison between Clinically Used Irregular Fields Shielded by Cerrobend and Standard Lead Blocks. J Biomed Phys Eng. 2015 Jun;5(2):77–82. X-126157733
3367 Farmer C, Butter E, Mazurek MO, . Aggression in children with autism spectrum disorders and a clinic-referred comparison group. Autism. 2015 Apr;19(3):281–91. doi: 10.1177/1362361313518995. X-124497627
3368 Fein E. Making meaningful worlds: role-playing subcultures and the autism spectrum. Cult Med Psychiatry. 2015 Jun;39(2):299–321. doi: 10.1007/s11013-015-9443-x. X-125812848
3369 Feinberg JI, Bakulski KM, Jaffe AE, . Paternal sperm DNA methylation associated with early signs of autism risk in an autism-enriched cohort. Int J Epidemiol. 2015 Aug;44(4):1199–210. doi: 10.1093/ije/dyv028. X-125878217
3370 Fejzo MS, Magtira A, Schoenberg FP, . Neurodevelopmental delay in children exposed in utero to hyperemesis gravidarum. Eur J Obstet Gynecol Reprod Biol. 2015 Jun;189:79–84. doi: 10.1016/j.ejogrb.2015.03.028. X-125898368
3371 Feldman MA, Hendry AM, Ward RA, . Behavioral development and sociodemographics of infants and young children at higher and lower risk for autism spectrum disorders. J Autism Dev Disord. 2015 May;45(5):1167–75. doi: 10.1007/s10803-014-2277-5. X-125326257
3372 Fenikile TS, Ellerbeck K, Filippi MK, . Barriers to autism screening in family medicine practice: a qualitative study. Prim Health Care Res Dev. 2015 Jul;16(4):356–66. doi: 10.1017/s1463423614000449. X-125367194
3373 Fenlon LR, Liu S, Gobius I, . Formation of functional areas in the cerebral cortex is disrupted in a mouse model of autism spectrum disorder. Neural Dev. 2015;10:10. doi: 10.1186/s13064-015-0033-y. X-125879444
3374 Fernandez-Andres MI, Pastor-Cerezuela G, Sanz-Cervera P, . A comparative study of sensory processing in children with and without Autism Spectrum Disorder in the home and classroom environments. Res Dev Disabil. 2015 Mar;38:202–12. doi: 10.1016/j.ridd.2014.12.034. X-125575284
3375 Fernell E, Bejerot S, Westerlund J, . Autism spectrum disorder and low vitamin D at birth: a sibling control study. Mol Autism. 2015;6:3. doi: 10.1186/2040-2392-6-3. X-125874075
3376 Feron F, Gepner B, Lacassagne E, . Olfactory stem cells reveal MOCOS as a new player in autism spectrum disorders. Mol Psychiatry. 2015 Aug 4 doi: 10.1038/mp.2015.106. X-1
3377 Ferreira-Vasques AT, Lamonica DA. Motor, linguistic, personal and social aspects of children with Down syndrome. J Appl Oral Sci. 2015 Aug;23(4):424–30. doi: 10.1590/1678-775720150102. X-126398516
3378 Fiene L, Brownlow C. Investigating interoception and body awareness in adults with and without autism spectrum disorder. Autism Res. 2015 Mar 25 doi: 10.1002/aur.1486. X-1
3379 Fieremans N, Van Esch H, de Ravel T, . Microdeletion of the escape genes KDM5C and IQSEC2 in a girl with severe intellectual disability and autistic features. Eur J Med Genet. 2015 May;58(5):324–7. doi: 10.1016/j.ejmg.2015.03.003. X-125858702
3380 Fiks AG, Mayne SL, Song L, . Changing patterns of alpha agonist medication use in children and adolescents 2009–2011. J Child Adolesc Psychopharmacol. 2015 May;25(4):362–7. doi: 10.1089/cap.2014.0122. X-1, X-325919708
3381 Filip C, Feragen KB, Lemvik JS, . Multidisciplinary Aspects of 104 Patients With Pierre Robin Sequence. Cleft Palate Craniofac J. 2015 Jan 2 doi: 10.1597/14-161. X-1
3382 Filliter JH, Longard J, Lawrence MA, . Positive affect in infant siblings of children diagnosed with autism spectrum disorder. J Abnorm Child Psychol. 2015 Apr;43(3):567–75. doi: 10.1007/s10802-014-9921-6. X-125117578
3383 Finn L, Ramasamy R, Dukes C, . Using WatchMinder to Increase the On-Task Behavior of Students with Autism Spectrum Disorder. J Autism Dev Disord. 2015 May;45(5):1408–18. doi: 10.1007/s10803-014-2300-x. X-1, X-325377769
3384 Fiske KE, Isenhower RW, Bamond MJ, . Assessing the value of token reinforcement for individuals with autism. J Appl Behav Anal. 2015 Summer;48(2):448–53. doi: 10.1002/jaba.207. X-1, X-3, X-425930718
3385 Fitzgerald J, Johnson K, Kehoe E, . Disrupted functional connectivity in dorsal and ventral attention networks during attention orienting in autism spectrum disorders. Autism Res. 2015 Apr;8(2):136–52. doi: 10.1002/aur.1430. X-125428212
3386 Flanagan T, Brodeur DA, Burack JA. A Point of Departure in the Comparison of Social and Nonsocial Visual Orienting Among Persons With Autism Spectrum Disorders. Autism Res. 2015 Oct;8(5):575–82. doi: 10.1002/aur.1472. X-125755149
3387 Fleury VP, Thompson JL, Wong C. Learning how to be a student: an overview of instructional practices targeting school readiness skills for preschoolers with autism spectrum disorder. Behav Modif. 2015 Jan;39(1):69–97. doi: 10.1177/0145445514551384. X-1, X-225261082
3388 Fleva E, Khan A. An examination of the leftward cradling bias among typically developing adults high on autistic traits. Laterality. 2015 Nov;20(6):711–22. doi: 10.1080/1357650x.2015.1046881. X-126120878
3389 Flippin M, Watson LR. Fathers’ and Mothers’ Verbal Responsiveness and the Language Skills of Young Children With Autism Spectrum Disorder. Am J Speech Lang Pathol. 2015 Aug 1;24(3):400–10. doi: 10.1044/2015_ajslp-13-0138. X-125836377
3390 Floris DL, Lai MC, Auer T, . Atypically rightward cerebral asymmetry in male adults with autism stratifies individuals with and without language delay. Hum Brain Mapp. 2015 Oct 23 doi: 10.1002/hbm.23023. X-1
3391 Foley D, Reid N, Neels A, . Profound hypomagnesaemia secondary to alternative therapy in a child with autism spectrum disorder. J Paediatr Child Health. 2015 Jul;51(7):744–5. doi: 10.1111/jpc.12946. X-1, X-3, X-426135158
3392 Fortea-Sevilla MS, Escandell-Bermudez MO, Castro-Sanchez JJ, . [Early development of language in small children with autism spectrum disorder using alternative systems]. Rev Neurol. 2015 Feb 25;60 Suppl 1:S31–5. X-325726821
3393 Fortuna RJ, Robinson L, Smith TH, . Health Conditions and Functional Status in Adults with Autism: A Cross-Sectional Evaluation. J Gen Intern Med. 2015 Sep 11 doi: 10.1007/s11606-015-3509-x. X-1
3394 Foss-Feig JH, McPartland JC, Anticevic A, . Re-conceptualizing ASD Within a Dimensional Framework: Positive, Negative, and Cognitive Feature Clusters. J Autism Dev Disord. 2015 Aug 13 doi: 10.1007/s10803-015-2539-x. X-1
3395 Foti F, De Crescenzo F, Vivanti G, . Implicit learning in individuals with autism spectrum disorders: a meta-analysis. Psychol Med. 2015 Apr;45(5):897–910. doi: 10.1017/s0033291714001950. X-1, X-225126858
3396 Foulkes L, Bird G, Gokcen E, . Common and distinct impacts of autistic traits and alexithymia on social reward. PLoS One. 2015;10(4):e0121018. doi: 10.1371/journal.pone.0121018. X-125853670
3397 Fountain C, Zhang Y, Kissin DM, . Association between assisted reproductive technology conception and autism in California, 1997–2007. Am J Public Health. 2015 May;105(5):963–71. doi: 10.2105/ajph.2014.302383. X-125790396
3398 Foxe JJ, Molholm S, Del Bene VA, . Severe multisensory speech integration deficits in high-functioning school-aged children with Autism Spectrum Disorder (ASD) and their resolution during early adolescence. Cereb Cortex. 2015 Feb;25(2):298–312. doi: 10.1093/cercor/bht213. X-123985136
3399 Fraley H. See Me, See My Child: Glimpses into Autism Spectrum Disorder. J Christ Nurs. 2015 Oct–Dec;32(4):212–8. X-126548173
3400 Frazier TW, Embacher R, Tilot AK, . Molecular and phenotypic abnormalities in individuals with germline heterozygous PTEN mutations and autism. Mol Psychiatry. 2015 Sep;20(9):1132–8. doi: 10.1038/mp.2014.125. X-125288137
3401 Freyberg J, Robertson C, Baron-Cohen S. Atypical Binocular Rivalry Dynamics of Simple and Complex Stimuli in Autism. J Vis. 2015 Sep 1;15(12):643. doi: 10.1167/15.12.643. X-1
3402 Friedrich EV, Sivanathan A, Lim T, . An Effective Neurofeedback Intervention to Improve Social Interactions in Children with Autism Spectrum Disorder. J Autism Dev Disord. 2015 Jul 26 doi: 10.1007/s10803-015-2523-5. X-3
3403 Frisch M, Simonsen J. Ritual circumcision and risk of autism spectrum disorder in 0- to 9-year-old boys: national cohort study in Denmark. J R Soc Med. 2015 Jul;108(7):266–79. doi: 10.1177/0141076814565942. X-125573114
3404 Frolli A, Piscopo S, Conson M. Developmental changes in cognitive and behavioural functioning of adolescents with fragile-X syndrome. J Intellect Disabil Res. 2015 Jul;59(7):613–21. doi: 10.1111/jir.12165. X-125160119
3405 Frye RE, Slattery J, MacFabe DF, . Approaches to studying and manipulating the enteric microbiome to improve autism symptoms. Microb Ecol Health Dis. 2015;26:26878. doi: 10.3402/mehd.v26.26878. X-125956237
3406 Fu SB, Penrod B, Fernand JK, . The Effects of Modeling Contingencies in the Treatment of Food Selectivity in Children With Autism. Behav Modif. 2015 Jul 1 doi: 10.1177/0145445515592639. X-1, X-3, X-4
3407 Fuentes-Albero M, Puig-Alcaraz C, Cauli O. Lead excretion in spanish children with autism spectrum disorder. Brain Sci. 2015;5(1):58–68. doi: 10.3390/brainsci5010058. X-125692508
3408 Fueyo M, Caldwell T, Mattern SB, . The Health Home: A Service Delivery Model for Autism and Intellectual Disability. Psychiatr Serv. 2015 Jul 1:appips201400443. doi: 10.1176/appi.ps.201400443. X-1
3409 Fukuhara H, Inoue K, Kurabayashi A, . Performance of 5-aminolevulinic-acid-based photodynamic diagnosis for radical prostatectomy. BMC Urol. 2015;15:78. doi: 10.1186/s12894-015-0073-y. X-126232024
3410 Fukuhara H, Kureishi M, Khoda T, . The Utility of a Flexible Fluorescence-Cystoscope with a Twin Mode Monitor for the 5-Aminolevulinic Acid-Mediated Photodynamic Diagnosis of Bladder Cancer. PLoS One. 2015;10(9):e0136416. doi: 10.1371/journal.pone.0136416. X-126332041
3411 Fung SC. Increasing the Social Communication of a Boy With Autism Using Animal-assisted Play Therapy: A Case Report. Adv Mind Body Med. 2015 Summer;29(3):27–31. X-3, X-4
3412 Furst A, Thron J, Scheele D, . The neuropeptide oxytocin modulates consumer brand relationships. Sci Rep. 2015;5:14960. doi: 10.1038/srep14960. X-126449882
3413 Gabriels RL, Pan Z, Dechant B, . Randomized Controlled Trial of Therapeutic Horseback Riding in Children and Adolescents With Autism Spectrum Disorder. J Am Acad Child Adolesc Psychiatry. 2015 Jul;54(7):541–9. doi: 10.1016/j.jaac.2015.04.007. X-126088658
3414 Gadke DL, McKinney C, Oliveros A. Autism Spectrum Disorder Symptoms and Comorbidity in Emerging Adults. Child Psychiatry Hum Dev. 2015 May 21 doi: 10.1007/s10578-015-0556-9. X-1
3415 Gal E, Lamash L, Bauminger-Zviely N, . Using Multitouch Collaboration Technology to Enhance Social Interaction of Children with High-Functioning Autism. Phys Occup Ther Pediatr. 2015 Sep 30:1–12. doi: 10.3109/01942638.2015.1040572. X-3
3416 Gal E, Selanikyo E, Erez AB, . Integration in the Vocational World: How Does It Affect Quality of Life and Subjective Well-Being of Young Adults with ASD. Int J Environ Res Public Health. 2015 Sep;12(9):10820–32. doi: 10.3390/ijerph120910820. X-126404341
3417 Gamsiz ED, Sciarra LN, Maguire AM, . Discovery of Rare Mutations in Autism: Elucidating Neurodevelopmental Mechanisms. Neurotherapeutics. 2015 Jul;12(3):553–71. doi: 10.1007/s13311-015-0363-9. X-126105128
3418 Ganai SA, Ramadoss M, Mahadevan V. Histone Deacetylase (HDAC) Inhibitors-emerging roles in neuronal memory, learning, synaptic plasticity and neural regeneration. Curr Neuropharmacol. 2015 Oct 21. X-1
3419 Gandin I, Faletra F, Faletra F, . Excess of runs of homozygosity is associated with severe cognitive impairment in intellectual disability. Genet Med. 2015 May;17(5):396–9. doi: 10.1038/gim.2014.118. X-125232855
3420 Garbacz SA, McIntyre LL. Conjoint Behavioral Consultation for Children With Autism Spectrum Disorder. Sch Psychol Q. 2015 Feb 16 doi: 10.1037/spq0000114. X-3, X-4
3421 Gardner SJ, Gulam M, Song K, . Generation and verification of QFix kVue Calypso-compatible couch top model for a dedicated stereotactic linear accelerator with FFF beams. J Appl Clin Med Phys. 2015;16(4):5441. X-126219010
3422 Garg S, Plasschaert E, Descheemaeker MJ, . Autism spectrum disorder profile in neurofibromatosis type I. J Autism Dev Disord. 2015 Jun;45(6):1649–57. doi: 10.1007/s10803-014-2321-5. X-125475362
3423 Gargaro BA, May T, Tonge BJ, . Attentional Mechanisms in Autism, ADHD, and Autism-ADHD Using a Local-Global Paradigm. J Atten Disord. 2015 Sep 15 doi: 10.1177/1087054715603197. X-1
3424 Gazina EV, Leaw BT, Richards KL, . ‘Neonatal’ Nav1.2 reduces neuronal excitability and affects seizure susceptibility and behaviour. Hum Mol Genet. 2015 Mar 1;24(5):1457–68. doi: 10.1093/hmg/ddu562. X-125378553
3425 Gee B, Thompson K, Pierce A, . The effectiveness of auditory stimulation in children with autism spectrum disorders: A case–control study. International Journal of Therapy & Rehabilitation. 2015;22(1):36–46 11p. Language: English. Entry Date: 20150116. Revision Date: 20150820. Publication Type: Journal Article. X-1, X-3, X-4
3426 Gengoux GW, Berquist KL, Salzman E, . Pivotal Response Treatment Parent Training for Autism: Findings from a 3-Month Follow-Up Evaluation. J Autism Dev Disord. 2015 Sep;45(9):2889–98. doi: 10.1007/s10803-015-2452-3. X-1, X-325911977
3427 Gentry T, Kriner R, Sima A, . Reducing the need for personal supports among workers with autism using an iPod Touch as an assistive technology: delayed randomized control trial. J Autism Dev Disord. 2015 Mar;45(3):669–84. doi: 10.1007/s10803-014-2221-8. X-125212414
3428 Geoffroy PA, Etain B, Franchi JA, . Melatonin and Melatonin Agonists as Adjunctive Treatments in Bipolar Disorders. Curr Pharm Des. 2015;21(23):3352–8. X-126088111
3429 Geretsegger M, Holck U, Carpente JA, . Common Characteristics of Improvisational Approaches in Music Therapy for Children with Autism Spectrum Disorder: Developing Treatment Guidelines. J Music Ther. 2015 Summer;52(2):258–81. doi: 10.1093/jmt/thv005. X-1, X-326019303
3430 Germain B, Eppinger MA, Mostofsky SH, . Recent Advances in Understanding and Managing Autism Spectrum Disorders. J Child Neurol. 2015 Sep 2 doi: 10.1177/0883073815601499. X-1, X-2
3431 Gerow S, Rispoli M, Boles MB, . An analysis of contingency statements in a DRO procedure: A case report. Dev Neurorehabil. 2015 Jun;18(3):203–8. doi: 10.3109/17518423.2013.809812. X-123870002
3432 Gershon ES, Grennan KS. Genetic and genomic analyses as a basis for new diagnostic nosologies. Dialogues Clin Neurosci. 2015 Mar;17(1):69–78. X-125987865
3433 Gesundheit B, Ashwood P, Keating A, . Therapeutic properties of mesenchymal stem cells for autism spectrum disorders. Med Hypotheses. 2015 Mar;84(3):169–77. doi: 10.1016/j.mehy.2014.12.016. X-1, X-2, X-325592283
3434 Gettings S, Franco F, Santosh PJ. Facilitating support groups for siblings of children with neurodevelopmental disorders using audio-conferencing: a longitudinal feasibility study. Child Adolesc Psychiatry Ment Health. 2015;9:8. doi: 10.1186/s13034-015-0041-z. X-125866558
3435 Ghaleiha A, Rasa SM, Nikoo M, . A pilot double-blind placebo-controlled trial of pioglitazone as adjunctive treatment to risperidone: Effects on aberrant behavior in children with autism. Psychiatry Res. 2015 Sep 30;229(1–2):181–7. doi: 10.1016/j.psychres.2015.07.043.26208985
3436 Ghanizadeh A, Ayoobzadehshirazi A. A randomized double-blind placebo-controlled clinical trial of adjuvant buspirone for irritability in autism. Pediatr Neurol. 2015 Jan;52(1):77–81. doi: 10.1016/j.pediatrneurol.2014.09.017.25451017
3437 Ghanizadeh A, Berk M. Beta-lactam antibiotics as a possible novel therapy for managing epilepsy and autism, a case report and review of literature. Iran J Child Neurol. 2015 Winter;9(1):99–102. X-125767546
3438 Ghanizadeh A, Tordjman S, Jaafari N. Aripiprazole for treating irritability in children & adolescents with autism: A systematic review. Indian J Med Res. 2015 Sep;142(3):269–75. doi: 10.4103/0971-5916.166584. X-2, X-326458342
3439 Gilani SZ, Tan DW, Russell-Smith SN, . Sexually dimorphic facial features vary according to level of autistic-like traits in the general population. J Neurodev Disord. 2015;7(1):14. doi: 10.1186/s11689-015-9109-6. X-125901187
3440 Gillam SL, Hartzheim D, Studenka B, . Narrative Intervention for Children With Autism Spectrum Disorder (ASD). J Speech Lang Hear Res. 2015 Jun;58(3):920–33. doi: 10.1044/2015_jslhr-l-14-0295. X-3, X-425837265
3441 Gillberg IC, Helles A, Billstedt E, . Boys with Asperger Syndrome Grow Up: Psychiatric and Neurodevelopmental Disorders 20 Years After Initial Diagnosis. J Autism Dev Disord. 2015 Jul 26 doi: 10.1007/s10803-015-2544-0. X-1
3442 Ginn NC, Clionsky LN, Eyberg SM, . Child-Directed Interaction Training for Young Children With Autism Spectrum Disorders: Parent and Child Outcomes. J Clin Child Adolesc Psychol. 2015 Mar 18:1–9. doi: 10.1080/15374416.2015.1015135. X-1
3443 Giovagnoli G, Postorino V, Fatta LM, . Behavioral and emotional profile and parental stress in preschool children with autism spectrum disorder. Res Dev Disabil. 2015 Oct–Nov;45–46:411–21. doi: 10.1016/j.ridd.2015.08.006. X-1
3444 Giovannetti T, Seligman SC, Britnell P, . Differential effects of goal cues on everyday action errors in Alzheimer’s disease versus Parkinson’s disease dementia. Neuropsychology. 2015 Jul;29(4):592–602. doi: 10.1037/neu0000167. X-125495833
3445 Gipson TT, Poretti A, Thomas EA, . Autism Phenotypes in Tuberous Sclerosis Complex: Diagnostic and Treatment Considerations. J Child Neurol. 2015 Aug 24 doi: 10.1177/0883073815600871. X-1
3446 Globerson E, Amir N, Kishon-Rabin L, . Prosody recognition in adults with high-functioning autism spectrum disorders: from psychoacoustics to cognition. Autism Res. 2015 Apr;8(2):153–63. doi: 10.1002/aur.1432. X-125428545
3447 Goddard MN, Swaab H, Rombouts SA, . Neural systems for social cognition: gray matter volume abnormalities in boys at high genetic risk of autism symptoms, and a comparison with idiopathic autism spectrum disorder. Eur Arch Psychiatry Clin Neurosci. 2015 Aug 2 doi: 10.1007/s00406-015-0623-z. X-1
3448 Goin-Kochel RP, Mire SS, Dempsey AG. Emergence of autism spectrum disorder in children from simplex families: relations to parental perceptions of etiology. J Autism Dev Disord. 2015 May;45(5):1451–63. doi: 10.1007/s10803-014-2310-8. X-125398603
3449 Goitia V, Oquendo M, Stratton R. Case of 7p22.1 Microduplication Detected by Whole Genome Microarray (REVEAL) in Workup of Child Diagnosed with Autism. Case Rep Genet. 2015;2015:212436. doi: 10.1155/2015/212436. X-125893121
3450 Goldingay S, Stagnitti K, Sheppard L, . An intervention to improve social participation for adolescents with autism spectrum disorder: pilot study. Dev Neurorehabil. 2015 Apr;18(2):122–30. doi: 10.3109/17518423.2013.855275. X-124206240
3451 Goldman S, DeNigris D. Parents’ strategies to elicit autobiographical memories in autism spectrum disorders, developmental language disorders and typically developing children. J Autism Dev Disord. 2015 May;45(5):1464–73. doi: 10.1007/s10803-014-2271-y. X-125312278
3452 Gona JK, Newton CR, Rimba K, . Parents’ and Professionals’ Perceptions on Causes and Treatment Options for Autism Spectrum Disorders (ASD) in a Multicultural Context on the Kenyan Coast. PLoS One. 2015;10(8):e0132729. doi: 10.1371/journal.pone.0132729. X-126267668
3453 Gong Y, Du Y, Li H, . Parenting stress and affective symptoms in parents of autistic children. Sci China Life Sci. 2015 Oct;58(10):1036–43. doi: 10.1007/s11427-012-4293-z. X-126335730
3454 Gonsiorowski A, Williamson RA, Robins DL. Brief Report: Imitation of Object-Directed Acts in Young Children with Autism Spectrum Disorders. J Autism Dev Disord. 2015 Sep 19 doi: 10.1007/s10803-015-2596-1. X-1
3455 Gonzales HK, O’Reilly M, Lang R, . Research involving anxiety in non-human primates has potential implications for the assessment and treatment of anxiety in autism spectrum disorder: A translational literature review. Dev Neurorehabil. 2015 Aug 24:1–18. doi: 10.3109/17518423.2014.941117. X-1
3456 Gonzalez EC, Summers C, Mueller V, . Developmental Surveillance and Referral in a Traditionally Medically Underserved Border Community. Matern Child Health J. 2015 Nov;19(11):2323–8. doi: 10.1007/s10995-015-1741-y. X-126386709
3457 Goodkind MS, Sturm VE, Ascher EA, . Emotion recognition in frontotemporal dementia and Alzheimer’s disease: A new film-based assessment. Emotion. 2015 Aug;15(4):416–27. doi: 10.1037/a0039261. X-126010574
3458 Goodwin A, Fein D, Naigles L. The role of maternal input in the development of wh-question comprehension in autism and typical development. Journal of Child Language. 2015;42(1):32–63 32p. doi: 10.1017/S0305000913000524. Language: English. Entry Date: 20141208. Revision Date: 20150820. Publication Type: Journal Article. X-124461930
3459 Gopinath N, Muneer AK, Unnikrishnan S, . Children (10–12 years age) of women with epilepsy have lower intelligence, attention and memory: Observations from a prospective cohort case control study. Epilepsy Res. 2015 Sep 9;117:58–62. doi: 10.1016/j.eplepsyres.2015.09.003. X-126418668
3460 Gordon EA, Corbitt C. Investigation of pre-pubertal sex differences in wheel running and social behavior in three mouse strains. J Ethol. 2015 Aug;33(3):177–87. doi: 10.1007/s10164-015-0429-5. X-126316671
3461 Gordon K, Murin M, Baykaner O, . A randomised controlled trial of PEGASUS, a psychoeducational programme for young people with high-functioning autism spectrum disorder. J Child Psychol Psychiatry. 2015 Apr;56(4):468–76. doi: 10.1111/jcpp.12304. X-125132516
3462 Gori I, Giuliano A, Muratori F, . Gray Matter Alterations in Young Children with Autism Spectrum Disorders: Comparing Morphometry at the Voxel and Regional Level. J Neuroimaging. 2015 Nov;25(6):866–74. doi: 10.1111/jon.12280. X-126214066
3463 Gotham K, Marvin AR, Taylor JL, . Characterizing the daily life, needs, and priorities of adults with autism spectrum disorder from Interactive Autism Network data. Autism. 2015 Oct;19(7):794–804. doi: 10.1177/1362361315583818. X-125964655
3464 Gotham K, Unruh K, Lord C. Depression and its measurement in verbal adolescents and adults with autism spectrum disorder. Autism. 2015 May;19(4):491–504. doi: 10.1177/1362361314536625. X-124916450
3465 Gozes I, Yeheskel A, Pasmanik-Chor M. Activity-dependent neuroprotective protein (ADNP): a case study for highly conserved chordata-specific genes shaping the brain and mutated in cancer. J Alzheimers Dis. 2015;45(1):57–73. doi: 10.3233/jad-142490. X-125428252
3466 Graham S, Abbott A, Nair A, . The Influence of Task Difficulty and Participant Age on Balance Control in ASD. Journal of Autism & Developmental Disorders. 2015;45(5):1419–27 9p. doi: 10.1007/s10803-014-2303-7. Language: English. Entry Date: 20150424. Revision Date: 20150710. Publication Type: Journal Article. X-125381191
3467 Grahame V, Brett D, Dixon L, . Managing Repetitive Behaviours in Young Children with Autism Spectrum Disorder (ASD): Pilot Randomised Controlled Trial of a New Parent Group Intervention. J Autism Dev Disord. 2015 Oct;45(10):3168–82. doi: 10.1007/s10803-015-2474-x. X-126036646
3468 Grandgeorge M, Bourreau Y, Alavi Z, . Interest towards human, animal and object in children with autism spectrum disorders: an ethological approach at home. European Child & Adolescent Psychiatry. 2015;24(1):83–93 11p. doi: 10.1007/s00787-014-0528-9. Language: English. Entry Date: 20150115. Revision Date: 20150710. Publication Type: Journal Article. X-1, X-324590630
3469 Grange P, Menashe I, Hawrylycz M. Cell-type-specific neuroanatomy of cliques of autism-related genes in the mouse brain. Front Comput Neurosci. 2015;9:55. doi: 10.3389/fncom.2015.00055. X-126074809
3470 Grant N, Rodger S, Hoffmann T. Intervention decision-making processes and information preferences of parents of children with autism spectrum disorders. Child Care Health Dev. 2015 Oct 22 doi: 10.1111/cch.12296. X-1
3471 Grant N, Rodger S, Hoffmann T. Evaluation of Autism-Related Health Information on the Web. J Appl Res Intellect Disabil. 2015 Jul;28(4):276–82. doi: 10.1111/jar.12127. X-125224690
3472 Grapel JN, Cicchetti DV, Volkmar FR. Sensory features as diagnostic criteria for autism: sensory features in autism. Yale J Biol Med. 2015 Mar;88(1):69–71. X-125745375
3473 Gray PH, Edwards DM, O’Callaghan MJ, . Screening for autism spectrum disorder in very preterm infants during early childhood. Early Hum Dev. 2015 Apr;91(4):271–6. doi: 10.1016/j.earlhumdev.2015.02.007. X-125766314
3474 Grayson B, Leger M, Piercy C, . Assessment of disease-related cognitive impairments using the novel object recognition (NOR) task in rodents. Behav Brain Res. 2015 May 15;285:176–93. doi: 10.1016/j.bbr.2014.10.025. X-125447293
3475 Green J, Charman T, Pickles A, . Parent-mediated intervention versus no intervention for infants at high risk of autism: a parallel, single-blind, randomised trial. Lancet Psychiatry. 2015 Feb;2(2):133–40. doi: 10.1016/s2215-0366(14)00091-1. X-126359749
3476 Green JL, Rinehart N, Anderson V, . Autism spectrum disorder symptoms in children with ADHD: A community-based study. Res Dev Disabil. 2015 Oct 1;47:175–84. doi: 10.1016/j.ridd.2015.09.016. X-126433184
3477 Green RR, Bigler ED, Froehlich A, . Beery VMI performance in autism spectrum disorder. Child Neuropsychol. 2015 Aug 21:1–23. doi: 10.1080/09297049.2015.1056131. X-124344790
3478 Green SA, Hernandez L, Tottenham N, . Neurobiology of Sensory Overresponsivity in Youth With Autism Spectrum Disorders. JAMA Psychiatry. 2015 Aug;72(8):778–86. doi: 10.1001/jamapsychiatry.2015.0737. X-126061819
3479 Greenberg DM, Baron-Cohen S, Stillwell DJ, . Musical Preferences are Linked to Cognitive Styles. PLoS One. 2015;10(7):e0131151. doi: 10.1371/journal.pone.0131151. X-126200656
3480 Greener M. Research roundup: June 2015. Nurse Prescribing. 2015;13(6):274–6 3p. Language: English. Entry Date: 20150616. Revision Date: 20151008. Publication Type: Journal Article. Journal Subset: Double Blind Peer Reviewed. X-1, X-2
3481 Greger HK, Myhre AK, Lydersen S, . Previous maltreatment and present mental health in a high-risk adolescent population. Child Abuse Negl. 2015 Jul;45:122–34. doi: 10.1016/j.chiabu.2015.05.003. X-126003821
3482 Grice SJ, Liu JL, Webber C. Synergistic interactions between Drosophila orthologues of genes spanned by de novo human CNVs support multiple-hit models of autism. PLoS Genet. 2015 Mar;11(3):e1004998. doi: 10.1371/journal.pgen.1004998. X-125816101
3483 Griesi-Oliveira K, Acab A, Gupta AR, . Modeling non-syndromic autism and the impact of TRPC6 disruption in human neurons. Mol Psychiatry. 2015 Nov;20(11):1350–65. doi: 10.1038/mp.2014.141. X-125385366
3484 Griffin C, Lombardo MV, Auyeung B. Alexithymia in children with and without autism spectrum disorders. Autism Res. 2015 Oct 1 doi: 10.1002/aur.1569. X-1
3485 Grimm D, Assouline B, Piero A. [Schooling of patients exhibiting Autism Spectrum Disorders without mental retardation]. Encephale. 2015 Sep 7 doi: 10.1016/j.encep.2015.07.005. X-1
3486 Grinker RR, Kang-Yi CD, Ahmann C, . Cultural Adaptation and Translation of Outreach Materials on Autism Spectrum Disorder. J Autism Dev Disord. 2015 Aug;45(8):2329–36. doi: 10.1007/s10803-015-2397-6. X-125758819
3487 Groskreutz MP, Peters A, Groskreutz NC, . Increasing play-based commenting in children with autism spectrum disorder using a novel script-frame procedure. J Appl Behav Anal. 2015 Summer;48(2):442–7. doi: 10.1002/jaba.194. X-125891090
3488 Gross C, Hoffmann A, Bassell GJ, . Therapeutic Strategies in Fragile X Syndrome: From Bench to Bedside and Back. Neurotherapeutics. 2015 Jul;12(3):584–608. doi: 10.1007/s13311-015-0355-9. X-125986746
3489 Gross JA, Bureau A, Croteau J, . A genome-wide copy number variant study of suicidal behavior. PLoS One. 2015;10(5):e0128369. doi: 10.1371/journal.pone.0128369. X-126010658
3490 Grossman RB, Steinhart E, Mitchell T, . “Look who’s talking!” gaze patterns for implicit and explicit audio-visual speech synchrony detection in children with high-functioning autism. Autism Research. 2015 2015-08-26;8(3):307–16. doi: http://dx.doi.org/10.1002/aur.1447; 2015-27677-001. X-1, X-225620208
3491 Grossman RB, Steinhart E, Mitchell T, . “Look who’s talking!” Gaze Patterns for Implicit and Explicit Audio-Visual Speech Synchrony Detection in Children With High-Functioning Autism. Autism Res. 2015 Jun;8(3):307–16. doi: 10.1002/aur.1447. X-125620208
3492 Grove R, Roth I, Hoekstra RA. The motivation for special interests in individuals with autism and controls: Development and validation of the special interest motivation scale. Autism Res. 2015 Oct 24 doi: 10.1002/aur.1560. X-1
3493 Gu C, Shen T, An H, . Combined therapy of Di-Huang-Yi-Zhi with Donepezil in patients with Parkinson’s disease dementia. Neurosci Lett. 2015 Oct 8;606:13–7. doi: 10.1016/j.neulet.2015.08.019. X-126297124
3494 Gu X, Eilam-Stock T, Zhou T, . Autonomic and brain responses associated with empathy deficits in autism spectrum disorder. Hum Brain Mapp. 2015 Sep;36(9):3323–38. doi: 10.1002/hbm.22840. X-125995134
3495 Guastella AJ, Gray KM, Rinehart NJ, . The effects of a course of intranasal oxytocin on social behaviors in youth diagnosed with autism spectrum disorders: a randomized controlled trial. J Child Psychol Psychiatry. 2015 Apr;56(4):444–52. doi: 10.1111/jcpp.12305. X-125087908
3496 Guevara-Campos J, Gonzalez-Guevara L, Cauli O. Autism and intellectual disability associated with mitochondrial disease and hyperlactacidemia. Int J Mol Sci. 2015;16(2):3870–84. doi: 10.3390/ijms16023870. X-125679448
3497 Guinchat V, Cravero C, Diaz L, . Acute behavioral crises in psychiatric inpatients with autism spectrum disorder (ASD): recognition of concomitant medical or non-ASD psychiatric conditions predicts enhanced improvement. Res Dev Disabil. 2015 Mar;38:242–55. doi: 10.1016/j.ridd.2014.12.020. X-125575287
3498 Guy J, Perreault A, Mottron L, . A systematic examination of early perceptual influences on low-, mid and high-level visual abilities in Autism Spectrum Disorder. J Vis. 2015 Sep 1;15(12):644. doi: 10.1167/15.12.644. X-1
3499 Guyatt AL, Heron J, Knight Ble C, . Digit ratio and autism spectrum disorders in the Avon Longitudinal Study of Parents and Children: a birth cohort study. BMJ Open. 2015;5(8):e007433. doi: 10.1136/bmjopen-2014-007433. X-1
3500 Habibe RC, Ortega AO, Guare RO, . Risk factors for anterior traumatic dental injury in children and adolescents with autism spectrum disorders: a case-control study. Eur Arch Paediatr Dent. 2015 Oct 8 doi: 10.1007/s40368-015-0207-7. X-1
3501 Hadjikhani N, Zürcher NR, Rogier O, . Improving emotional face perception in autism with diuretic bumetanide: A proof-of-concept behavioral and functional brain imaging pilot study. Autism: The International Journal of Research & Practice. 2015;19(2):149–57 9p. doi: 10.1177/1362361313514141. Language: English. Entry Date: 20150130. Revision Date: 20150710. Publication Type: Journal Article. X-1, X-324343334
3502 Hagberg B, Billstedt E, Nyden A, . Asperger syndrome and nonverbal learning difficulties in adult males: self- and parent-reported autism, attention and executive problems. Eur Child Adolesc Psychiatry. 2015 Aug;24(8):969–77. doi: 10.1007/s00787-014-0646-4. X-125399237
3503 Hagen E, Shprung D, Minakova E, . Autism-Like Behavior in BTBR Mice Is Improved by Electroconvulsive Therapy. Neurotherapeutics. 2015 Jul;12(3):657–66. doi: 10.1007/s13311-015-0357-7. X-125916397
3504 Haigh SM, Heeger DJ, Dinstein I, . Cortical variability in the sensory-evoked response in autism. J Autism Dev Disord. 2015 May;45(5):1176–90. doi: 10.1007/s10803-014-2276-6. X-125326820
3505 Hall SS, Frank MC, Pusiol GT, . Quantifying naturalistic social gaze in fragile X syndrome using a novel eye tracking paradigm. Am J Med Genet B Neuropsychiatr Genet. 2015 Oct;168(7):564–72. doi: 10.1002/ajmg.b.32331. X-126079280
3506 Hall T, Kriz D, Duvall S, . Healthcare transition challenges faced by young adults with autism spectrum disorder. Clin Pharmacol Ther. 2015 Dec;98(6):573–5. doi: 10.1002/cpt.254. X-126300522
3507 Halladay AK, Bishop S, Constantino JN, . Sex and gender differences in autism spectrum disorder: summarizing evidence gaps and identifying emerging areas of priority. Mol Autism. 2015;6:36. doi: 10.1186/s13229-015-0019-y. X-126075049
3508 Hallbook T, Sjolander A, Amark P, . Effectiveness of the ketogenic diet used to treat resistant childhood epilepsy in Scandinavia. Eur J Paediatr Neurol. 2015 Jan;19(1):29–36. doi: 10.1016/j.ejpn.2014.09.005. X-125457511
3509 Han B, Tijus C, Le Barillier F, . Morphing technique reveals intact perception of object motion and disturbed perception of emotional expressions by low-functioning adolescents with Autism Spectrum Disorder. Res Dev Disabil. 2015 Dec;47:393–404. doi: 10.1016/j.ridd.2015.09.025. X-126513740
3510 Han Y, Xi QQ, Dai W, . Abnormal transsulfuration metabolism and reduced antioxidant capacity in Chinese children with autism spectrum disorders. Int J Dev Neurosci. 2015 Nov;46:27–32. doi: 10.1016/j.ijdevneu.2015.06.006. X-126150135
3511 Handen BL, Aman MG, Arnold LE, . Atomoxetine, Parent Training, and Their Combination in Children With Autism Spectrum Disorder and Attention-Deficit/Hyperactivity Disorder. J Am Acad Child Adolesc Psychiatry. 2015 Nov;54(11):905–15. doi: 10.1016/j.jaac.2015.08.013.26506581
3512 Hanne M. Diagnosis and Metaphor. Perspect Biol Med. 2015 Winter;58(1):35–52. doi: 10.1353/pbm.2015.0010. X-126657680
3513 Hanson E, Bernier R, Porche K, . The cognitive and behavioral phenotype of the 16p11.2 deletion in a clinically ascertained population. Biol Psychiatry. 2015 May 1;77(9):785–93. doi: 10.1016/j.biopsych.2014.04.021. X-125064419
3514 Haq SS, Kodak T, Kurtz-Nelson E, . Comparing the effects of massed and distributed practice on skill acquisition for children with autism. J Appl Behav Anal. 2015 Summer;48(2):454–9. doi: 10.1002/jaba.213. X-125962478
3515 Hardan AY, Gengoux GW, Berquist KL, . A randomized controlled trial of Pivotal Response Treatment Group for parents of children with autism. J Child Psychol Psychiatry. 2015 Aug;56(8):884–92. doi: 10.1111/jcpp.12354. X-125346345
3516 Hare DJ, Wood C, Wastell S, . Anxiety in Asperger’s syndrome: Assessment in real time. Autism. 2015 Jul;19(5):542–52. doi: 10.1177/1362361314531340. X-124811968
3517 Harfterkamp M, van der Meer D, van der Loo-Neus G, . No evidence for predictors of response to atomoxetine treatment of attention-deficit/hyperactivity disorder symptoms in children and adolescents with autism spectrum disorder. J Child Adolesc Psychopharmacol. 2015 May;25(4):372–5. doi: 10.1089/cap.2014.0142. X-225919900
3518 Harstad EB, Fogler J, Sideridis G, . Comparing Diagnostic Outcomes of Autism Spectrum Disorder Using DSM-IV-TR and DSM-5 Criteria. J Autism Dev Disord. 2015 May;45(5):1437–50. doi: 10.1007/s10803-014-2306-4. X-125384720
3519 Hartley SL, Schultz HM. Support needs of fathers and mothers of children and adolescents with autism spectrum disorder. J Autism Dev Disord. 2015 Jun;45(6):1636–48. doi: 10.1007/s10803-014-2318-0. X-125433405
3520 Hasenstab K, Sugar CA, Telesca D, . Identifying longitudinal trends within EEG experiments. Biometrics. 2015 Jul 20 doi: 10.1111/biom.12347. X-1
3521 Hashemi B, Bassett A, Chitayat D, . Deletion of 15q11.2(BP1–BP2) region: Further evidence for lack of phenotypic specificity in a pediatric population. Am J Med Genet A. 2015 Sep;167(9):2098–102. doi: 10.1002/ajmg.a.37134. X-1
3522 Heavner K, Burstyn I. A Simulation Study of Categorizing Continuous Exposure Variables Measured with Error in Autism Research: Small Changes with Large Effects. Int J Environ Res Public Health. 2015 Aug;12(8):10198–234. doi: 10.3390/ijerph120810198. X-126305250
3523 Heberling C, Dhurjati P. Novel systems modeling methodology in comparative microbial metabolomics: identifying key enzymes and metabolites implicated in autism spectrum disorders. Int J Mol Sci. 2015;16(4):8949–67. doi: 10.3390/ijms16048949. X-125913376
3524 Hedley D, Nevill RE, Monroy-Moreno Y, . Efficacy of the ADEC in Identifying Autism Spectrum Disorder in Clinically Referred Toddlers in the US. J Autism Dev Disord. 2015 Aug;45(8):2337–48. doi: 10.1007/s10803-015-2398-5. X-125737020
3525 Hedvall A, Westerlund J, Fernell E, . Preschoolers with Autism Spectrum Disorder Followed for 2 Years: Those Who Gained and Those Who Lost the Most in Terms of Adaptive Functioning Outcome. J Autism Dev Disord. 2015 Nov;45(11):3624–33. doi: 10.1007/s10803-015-2509-3. X-126123008
3526 Heffler KF, Oestreicher LM. Causation model of autism: Audiovisual brain specialization in infancy competes with social brain networks. Med Hypotheses. 2015 Jun 27 doi: 10.1016/j.mehy.2015.06.019. X-1
3527 Heidary A, Hosseini Shahidi L, Mohammadpuor A. Spiritual Journey in Mothers’ Lived Experiences of Caring for Children With Autism Spectrum Disorders. Glob J Health Sci. 2015 Nov;7(6):79–87. doi: 10.5539/gjhs.v7n6p79. X-1
3528 Heisler JM, Morales J, Donegan JJ, . The attentional set shifting task: a measure of cognitive flexibility in mice. J Vis Exp. 2015(96)doi: 10.3791/51944. X-1
3529 Helles A, Gillberg CI, Gillberg C, . Asperger syndrome in males over two decades: stability and predictors of diagnosis. J Child Psychol Psychiatry. 2015 Jun;56(6):711–8. doi: 10.1111/jcpp.12334. X-125283685
3530 Hellings JA, Jadhav M, Jain S, . Low Dose Loxapine: Neuromotor Side Effects and Tolerability in Autism Spectrum Disorders. J Child Adolesc Psychopharmacol. 2015 Oct;25(8):618–24. doi: 10.1089/cap.2014.0145. X-1, X-326485086
3531 Hellings JA, Reed G, Cain SE, . Loxapine add-on for adolescents and adults with autism spectrum disorders and irritability. J Child Adolesc Psychopharmacol. 2015 Mar;25(2):150–9. doi: 10.1089/cap.2014.0003. X-125782098
3532 Hellwig S, Frings L, Amtage F, . 18F-FDG PET Is an Early Predictor of Overall Survival in Suspected Atypical Parkinsonism. J Nucl Med. 2015 Oct;56(10):1541–6. doi: 10.2967/jnumed.115.159822. X-126229141
3533 Hepburn SL, Blakeley-Smith A, Wolff B, . Telehealth delivery of cognitive-behavioral intervention to youth with autism spectrum disorder and anxiety: A pilot study. Autism. 2015 Apr 20 doi: 10.1177/1362361315575164. X-1, X-3
3534 Herbrecht E, Kievit E, Spiegel R, . Become Related: FIAS, an Intensive Early Intervention for Young Children with Autism Spectrum Disorders. Psychopathology. 2015;48(3):162–72. doi: 10.1159/000375504. X-3, X-425832916
3535 Herndon JM. Evidence of Coal-Fly-Ash Toxic Chemical Geoengineering in the Troposphere: Consequences for Public Health. Int J Environ Res Public Health. 2015 Aug;12(8):9375–90. doi: 10.3390/ijerph120809375. X-126270671
3536 Herpers PC, Klip H, Rommelse NN, . Associations between high callous-unemotional traits and quality of life across youths with non-conduct disorder diagnoses. Eur Child Adolesc Psychiatry. 2015 Sep 11 doi: 10.1007/s00787-015-0766-5. X-1
3537 Herrmann S. Counting Sheep: Sleep Disorders in Children With Autism Spectrum Disorders. J Pediatr Health Care. 2015 Aug 22 doi: 10.1016/j.pedhc.2015.07.003. X-1
3538 Hidalgo NJ, Mc IL, Mc WE. Sociodemographic differences in parental satisfaction with an autism spectrum disorder diagnosis. J Intellect Dev Disabil. 2015;40(2):147–55. doi: 10.3109/13668250.2014.994171. X-126213482
3539 Hidding E, Swaab H, de Sonneville LM, . Intellectual functioning in relation to autism and ADHD symptomatology in children and adolescents with 22q11.2 deletion syndrome. J Intellect Disabil Res. 2015 Sep;59(9):803–15. doi: 10.1111/jir.12187. X-125683771
3540 Higdon R, Earl RK, Stanberry L, . The promise of multi-omics and clinical data integration to identify and target personalized healthcare approaches in autism spectrum disorders. Omics. 2015 Apr;19(4):197–208. doi: 10.1089/omi.2015.0020. X-125831060
3541 Higuchi Y, Uchitomi Y, Fujimori M, . Exploring autistic-like traits relating to empathic attitude and psychological distress in hospital pharmacists. Int J Clin Pharm. 2015 Dec;37(6):1258–66. doi: 10.1007/s11096-015-0204-2. X-126441314
3542 Hiller RM, Young RL, Weber N. Sex differences in pre-diagnosis concerns for children later diagnosed with autism spectrum disorder. Autism. 2015 Feb 25 doi: 10.1177/1362361314568899. X-1
3543 Hiraishi H, Kikuchi M, Yoshimura Y, . Unusual developmental pattern of brain lateralization in young boys with autism spectrum disorder: Power analysis with child-sized magnetoencephalography. Psychiatry Clin Neurosci. 2015 Mar;69(3):153–60. doi: 10.1111/pcn.12261. X-125439739
3544 Hirvikoski T, Blomqvist M. High self-perceived stress and poor coping in intellectually able adults with autism spectrum disorder. Autism. 2015 Aug;19(6):752–7. doi: 10.1177/1362361314543530. X-125073750
3545 Hobson JA, Tarver L, Beurkens N, . The Relation between Severity of Autism and Caregiver-Child Interaction: a Study in the Context of Relationship Development Intervention. J Abnorm Child Psychol. 2015 Aug 23 doi: 10.1007/s10802-015-0067-y. X-1, X-3
3546 Hobson P, Meara J. Mild cognitive impairment in Parkinson’s disease and its progression onto dementia: a 16-year outcome evaluation of the Denbighshire cohort. Int J Geriatr Psychiatry. 2015 Oct;30(10):1048–55. doi: 10.1002/gps.4261. X-125676160
3547 Hock R, Kinsman A, Ortaglia A. Examining treatment adherence among parents of children with autism spectrum disorder. Disabil Health J. 2015 Jul;8(3):407–13. doi: 10.1016/j.dhjo.2014.10.005. X-125595296
3548 Hodgetts S, Zwaigenbaum L, Nicholas D. Profile and predictors of service needs for families of children with autism spectrum disorders. Autism. 2015 Aug;19(6):673–83. doi: 10.1177/1362361314543531. X-125073749
3549 Hofmann SG, Fang A, Brager DN. Effect of intranasal oxytocin administration on psychiatric symptoms: A meta-analysis of placebo-controlled studies. Psychiatry Res. 2015 Aug 30;228(3):708–14. doi: 10.1016/j.psychres.2015.05.039. X-2, X-326094200
3550 Holmes GL, Tian C, Hernan AE, . Alterations in sociability and functional brain connectivity caused by early-life seizures are prevented by bumetanide. Neurobiol Dis. 2015 May;77:204–19. doi: 10.1016/j.nbd.2015.02.015. X-125766676
3551 Hong ER, Neely L, Rispoli MJ, . A comparison of general and explicit delay cues to reinforcement for tangible-maintained challenging behaviour. Dev Neurorehabil. 2015 Aug 24:1–7. doi: 10.3109/17518423.2013.874378. X-1, X-4
3552 Hong LJ, Jiang Q, Long S, . Valproic Acid Influences MTNR1A Intracellular Trafficking and Signaling in a beta-Arrestin 2-Dependent Manner. Mol Neurobiol. 2015 Jan 24 doi: 10.1007/s12035-014-9085-y. X-1
3553 Hongkaew Y, Ngamsamut N, Puangpetch A, . Hyperprolactinemia in Thai children and adolescents with autism spectrum disorder treated with risperidone. Neuropsychiatr Dis Treat. 2015;11:191–6. doi: 10.2147/ndt.s76276. X-1, X-325653528
3554 Horlin C, Black M, Falkmer M, . Proficiency of individuals with autism spectrum disorder at disembedding figures: A systematic review. Dev Neurorehabil. 2015 Aug 24:1–10. doi: 10.3109/17518423.2014.888102. X-1, X-2
3555 Howe YJ, O’Rourke JA, Yatchmink Y, . Female Autism Phenotypes Investigated at Different Levels of Language and Developmental Abilities. J Autism Dev Disord. 2015 Nov;45(11):3537–49. doi: 10.1007/s10803-015-2501-y. X-126100851
3556 Hranilovic D, Blazevic S, Stefulj J, . DNA Methylation Analysis of HTR2A Regulatory Region in Leukocytes of Autistic Subjects. Autism Res. 2015 Jul 7 doi: 10.1002/aur.1519. X-1
3557 Hu VW, Sarachana T, Sherrard RM, . Investigation of sex differences in the expression of RORA and its transcriptional targets in the brain as a potential contributor to the sex bias in autism. Mol Autism. 2015;6:7. doi: 10.1186/2040-2392-6-7. X-126056561
3558 Huang SF, Oi M, Taguchi A. Comprehension of figurative language in Taiwanese children with autism: The role of theory of mind and receptive vocabulary. Clin Linguist Phon. 2015 Aug;29(8–10):764–75. doi: 10.3109/02699206.2015.1027833. X-125909823
3559 Hudac CM, Kresse A, Aaronson B, . Modulation of mu attenuation to social stimuli in children and adults with 16p11.2 deletions and duplications. J Neurodev Disord. 2015;7(1):25. doi: 10.1186/s11689-015-9118-5. X-126213586
3560 Huguet G, Contejean Y, Doyen C. [Autism spectrum disorder and suicidality]. Encephale. 2015 Sep;41(4):362–9. doi: 10.1016/j.encep.2014.08.010. X-125200592
3561 Hui Z, Yongchao Z, Yongqing Z. Recent progresses in molecular genetics of autism spectrum disorders. Yi Chuan. 2015 Sep;37(9):845–54. doi: 10.16288/j.yczz.15-281. X-126399524
3562 Huijbregts SC, Loitfelder M, Rombouts SA, . Cerebral volumetric abnormalities in Neurofibromatosis type 1: associations with parent ratings of social and attention problems, executive dysfunction, and autistic mannerisms. J Neurodev Disord. 2015;7:32. doi: 10.1186/s11689-015-9128-3. X-126473019
3563 Hull MM, Madhavan D, Zaroff CM. Autistic spectrum disorder, epilepsy, and vagus nerve stimulation. Childs Nerv Syst. 2015 Aug;31(8):1377–85. doi: 10.1007/s00381-015-2720-8. X-125922052
3564 Hurwitz S, Watson LR. Joint attention revisited: Finding strengths among children with autism. Autism. 2015 Jul 6 doi: 10.1177/1362361315593536. X-1
3565 Huskens B, Palmen A, Van der Werff M, . Improving Collaborative Play Between Children with Autism Spectrum Disorders and Their Siblings: The Effectiveness of a Robot-Mediated Intervention Based on Lego((R)) Therapy. J Autism Dev Disord. 2015 Nov;45(11):3746–55. doi: 10.1007/s10803-014-2326-0. X-1, X-325428293
3566 Hustyi KM, Hall SS, Quintin EM, . The relationship between autistic symptomatology and independent living skills in adolescents and young adults with fragile X syndrome. J Autism Dev Disord. 2015 Jun;45(6):1836–44. doi: 10.1007/s10803-014-2342-0. X-125518824
3567 Hyman SL, Stewart PA, Foley J, . The Gluten-Free/Casein-Free Diet: A Double-Blind Challenge Trial in Children with Autism. J Autism Dev Disord. 2015 Sep 5 doi: 10.1007/s10803-015-2564-9.
3568 Iadarola S, Hetherington S, Clinton C, . Services for children with autism spectrum disorder in three, large urban school districts: Perspectives of parents and educators. Autism. 2015 Aug;19(6):694–703. doi: 10.1177/1362361314548078. X-125192859
3569 Iannuzzi DA, Cheng ER, Broder-Fingert S, . Brief report: Emergency department utilization by individuals with autism. J Autism Dev Disord. 2015 Apr;45(4):1096–102. doi: 10.1007/s10803-014-2251-2. X-125261249
3570 Igartua DE, Calienni MN, Feas DA, . Development of Nutraceutical Emulsions as Risperidone Delivery Systems: Characterization and Toxicological Studies. J Pharm Sci. 2015 Sep 11 doi: 10.1002/jps.24636. X-1
3571 Ingersoll B, Berger NI. Parent Engagement With a Telehealth-Based Parent-Mediated Intervention Program for Children With Autism Spectrum Disorders: Predictors of Program Use and Parent Outcomes. J Med Internet Res. 2015;17(10):e227. doi: 10.2196/jmir.4913. X-126443557
3572 Inoue K, Anai S, Fujimoto K, . Oral 5-aminolevulinic acid mediated photodynamic diagnosis using fluorescence cystoscopy for non-muscle-invasive bladder cancer: A randomized, double-blind, multicentre phase II/III study. Photodiagnosis Photodyn Ther. 2015 Jun;12(2):193–200. doi: 10.1016/j.pdpdt.2015.03.008. X-125843912
3573 Iourov IY, Vorsanova SG, Korostelev SA, . Long contiguous stretches of homozygosity spanning shortly the imprinted loci are associated with intellectual disability, autism and/or epilepsy. Mol Cytogenet. 2015;8:77. doi: 10.1186/s13039-015-0182-z. X-126478745
3574 Irwin J, Preston J, Brancazio L, . Development of an audiovisual speech perception app for children with autism spectrum disorders. Clin Linguist Phon. 2015 Jan;29(1):76–83. doi: 10.3109/02699206.2014.966395. X-3, X-425313714
3575 Ishii K, Kubo K, Endo T, . Neuronal Heterotopias Affect the Activities of Distant Brain Areas and Lead to Behavioral Deficits. J Neurosci. 2015 Sep 9;35(36):12432–45. doi: 10.1523/jneurosci.3648-14.2015. X-126354912
3576 Isomura T, Ogawa S, Shibasaki M, . Delayed disengagement of attention from snakes in children with autism. Front Psychol. 2015;6:241. doi: 10.3389/fpsyg.2015.00241. X-125784895
3577 Itahashi T, Yamada T, Watanabe H, . Alterations of local spontaneous brain activity and connectivity in adults with high-functioning autism spectrum disorder. Mol Autism. 2015;6:30. doi: 10.1186/s13229-015-0026-z. X-126023326
3578 Izadi-Najafabadi S, Mirzakhani-Araghi N, Miri-Lavasani N, . Implicit and explicit motor learning: Application to children with Autism Spectrum Disorder (ASD). Res Dev Disabil. 2015 Oct 9;47:284–96. doi: 10.1016/j.ridd.2015.09.020. X-126458260
3579 Izuwah DN, Okoh BA, Alikor EA. Clinical Pattern of Autism in Nigeria. Autism Res. 2015 Aug 25 doi: 10.1002/aur.1531. X-1
3580 Jaarsma P, Welin S. Autism, Accommodation and Treatment: A Rejoinder to Chong-Ming Lim’s Critique. Bioethics. 2015 Nov;29(9):684–5. doi: 10.1111/bioe.12183. X-1, X-226307242
3581 Jac Fredo AR, Kavitha G, Ramakrishnan S. Subcortical Region Segmentation using Fuzzy Based Augmented Lagrangian Multiphase Level Sets Method in Autistic MR Brain Images. Biomed Sci Instrum. 2015;51:323–31. X-125996735
3582 Jachim S, Warren PA, McLoughlin N, . Collinear facilitation and contour integration in autism: evidence for atypical visual integration. Front Hum Neurosci. 2015;9:115. doi: 10.3389/fnhum.2015.00115. X-125805985
3583 Jacob A, Scott M, Falkmer M, . The Costs and Benefits of Employing an Adult with Autism Spectrum Disorder: A Systematic Review. PLoS One. 2015;10(10):e0139896. doi: 10.1371/journal.pone.0139896. X-126445345
3584 Jameel L, Vyas K, Bellesi G, . Great Expectations: The Role of Rules in Guiding Pro-social Behaviour in Groups with High Versus Low Autistic Traits. J Autism Dev Disord. 2015 Aug;45(8):2311–22. doi: 10.1007/s10803-015-2393-x. X-125697738
3585 James DM, Hall A, Lombardo C, . A Video Feedback Intervention for Workforce Development: Exploring Staff Perspective Using Longitudinal Qualitative Methodology. J Appl Res Intellect Disabil. 2015 Mar 16 doi: 10.1111/jar.12161. X-1
3586 James S, Stevenson SW, Silove N, . Chelation for autism spectrum disorder (ASD). Cochrane Database Syst Rev. 2015 May 11;5:Cd010766. doi: 10.1002/14651858.CD010766.pub2. X-1, X-226114777
3587 Jamison TR, Schuttler JO. Examining social competence, self-perception, quality of life, and internalizing and externalizing symptoms in adolescent females with and without autism spectrum disorder: a quantitative design including between-groups and correlational analyses. Mol Autism. 2015;6:53. doi: 10.1186/s13229-015-0044-x. X-126388982
3588 Janvier YM, Harris JF, Coffield CN, . Screening for autism spectrum disorder in underserved communities: Early childcare providers as reporters. Autism. 2015 May 19 doi: 10.1177/1362361315585055. X-1
3589 Janzen LA, David D, Walker D, . Pre-Morbid Developmental Vulnerabilities in Children With Newly Diagnosed Acute Lymphoblastic Leukemia (ALL). Pediatr Blood Cancer. 2015 Dec;62(12):2183–8. doi: 10.1002/pbc.25692. X-126305495
3590 Jarvinen A, Ng R, Crivelli D, . Social functioning and autonomic nervous system sensitivity across vocal and musical emotion in Williams syndrome and autism spectrum disorder. Dev Psychobiol. 2015 Aug 6 doi: 10.1002/dev.21335. X-1
3591 Jeffries T, Crosland K, Miltenberger R. Evaluating a tablet application and differential reinforcement to increase eye contact in children with autism. J Appl Behav Anal. 2015 Oct 19 doi: 10.1002/jaba.262. X-3, X-4
3592 Jeha D, Usta I, Ghulmiyyah L, . A review of the risks and consequences of adolescent pregnancy. J Neonatal Perinatal Med. 2015 Mar 12 doi: 10.3233/npm-15814038. X-1
3593 Jenkins AK, Paterson C, Wang Y, . Neurexin 1 (NRXN1) splice isoform expression during human neocortical development and aging. Mol Psychiatry. 2015 Jul 28 doi: 10.1038/mp.2015.107. X-1
3594 Jenkins J, 3rd, Chow V, Blaskey L, . Auditory Evoked M100 Response Latency is Delayed in Children with 16p11.2 Deletion but not 16p11.2 Duplication. Cereb Cortex. 2015 Feb 11 doi: 10.1093/cercor/bhv008. X-1
3595 Jermoumi M, Korideck H, Bhagwat M, . Comprehensive quality assurance phantom for the small animal radiation research platform (SARRP). Phys Med. 2015 Jul;31(5):529–35. doi: 10.1016/j.ejmp.2015.04.010. X-125964129
3596 Jeste SS. Neurodevelopmental behavioral and cognitive disorders. Continuum (Minneap Minn). 2015 Jun;21(3 Behavioral Neurology and Neuropsychiatry):690–714. doi: 10.1212/01.CON.0000466661.89908.3c. X-126039849
3597 Jeste SS, Frohlich J, Loo SK. Electrophysiological biomarkers of diagnosis and outcome in neurodevelopmental disorders. Curr Opin Neurol. 2015 Apr;28(2):110–6. doi: 10.1097/wco.0000000000000181. X-125710286
3598 Jeste SS, Tuchman R. Autism Spectrum Disorder and Epilepsy: Two Sides of the Same Coin? J Child Neurol. 2015 Sep 14 doi: 10.1177/0883073815601501. X-1
3599 Jiang R. Walking on multiple disease-gene networks to prioritize candidate genes. J Mol Cell Biol. 2015 Jun;7(3):214–30. doi: 10.1093/jmcb/mjv008. X-1, X-225681405
3600 Jiang YV, Palm BE, DeBolt MC, . High-precision visual long-term memory in children with high-functioning autism. J Abnorm Psychol. 2015 May;124(2):447–56. doi: 10.1037/abn0000022. X-125436998
3601 Jin Y, Wee CY, Shi F, . Identification of infants at high-risk for autism spectrum disorder using multiparameter multiscale white matter connectivity networks. Hum Brain Mapp. 2015 Sep 14 doi: 10.1002/hbm.22957. X-1
3602 Jo H, Schieve LA, Rice CE, . Age at Autism Spectrum Disorder (ASD) Diagnosis by Race, Ethnicity, and Primary Household Language Among Children with Special Health Care Needs, United States, 2009–2010. Matern Child Health J. 2015 Aug;19(8):1687–97. doi: 10.1007/s10995-015-1683-4. X-125701197
3603 Johnco CJ, De Nadai AS, Lewin AB, . Defining Treatment Response and Symptom Remission for Anxiety Disorders in Pediatric Autism Spectrum Disorders Using the Pediatric Anxiety Rating Scale. J Autism Dev Disord. 2015 Oct;45(10):3232–42. doi: 10.1007/s10803-015-2483-9. X-1, X-326031924
3604 Johnco CJ, De Nadai AS, Lewin AB, . Erratum to: Defining Treatment Response and Symptom Remission for Anxiety Disorders in Pediatric Autism Spectrum Disorders Using the Pediatric Anxiety Rating Scale. J Autism Dev Disord. 2015 Oct;45(10):3243. doi: 10.1007/s10803-015-2554-y. X-126272676
3605 Johnson N, Van Hecke A. Increasing Autism Awareness in Inner-City Churches: A Brief Report. J Pediatr Nurs. 2015 May 15 doi: 10.1016/j.pedn.2015.04.008. X-1
3606 Johnstone CD, LaFontaine R, Poirier Y, . Modeling a superficial radiotherapy X-ray source for relative dose calculations. J Appl Clin Med Phys. 2015;16(3):5162. doi: 10.1120/jacmp.v16i3.5162. X-126103479
3607 Jones KB, Cottle K, Bakian A, . A description of medical conditions in adults with autism spectrum disorder: A follow-up of the 1980s Utah/UCLA Autism Epidemiologic Study. Autism. 2015 Jul 10 doi: 10.1177/1362361315594798. X-1
3608 Jones RM, Risi S, Wexler D, . How interview questions are placed in time influences caregiver description of social communication symptoms on the ADI-R. J Child Psychol Psychiatry. 2015 May;56(5):577–85. doi: 10.1111/jcpp.12325. X-125243378
3609 Jure R, Pogonza R, Rapin I. Autism Spectrum Disorders (ASD) in Blind Children: Very High Prevalence, Potentially Better Outlook. J Autism Dev Disord. 2015 Sep 25 doi: 10.1007/s10803-015-2612-5. X-1
3610 Jurecka A, Zikanova M, Kmoch S, . Adenylosuccinate lyase deficiency. J Inherit Metab Dis. 2015 Mar;38(2):231–42. doi: 10.1007/s10545-014-9755-y. X-125112391
3611 Jurnak F. The Pivotal Role of Aldehyde Toxicity in Autism Spectrum Disorder: The Therapeutic Potential of Micronutrient Supplementation. Nutr Metab Insights. 2015;8(Suppl 1):57–77. doi: 10.4137/nmi.s29531. X-127330305
3612 Kaat AJ, Lecavalier L. Reliability and Validity of Parent- and Child-Rated Anxiety Measures in Autism Spectrum Disorder. J Autism Dev Disord. 2015 Oct;45(10):3219–31. doi: 10.1007/s10803-015-2481-y. X-126036649
3613 Kabitzke PA, Simpson EH, Kandel ER, . Social behavior in a genetic model of dopamine dysfunction at different neurodevelopmental time points. Genes Brain Behav. 2015 Sep;14(7):503–15. doi: 10.1111/gbb.12233. X-126176662
3614 Kadak MT, Cetin I, Tarakcioglu MC, . Low Serum Level alpha-Synuclein and Tau Protein in Autism Spectrum Disorder Compared to Controls. Neuropediatrics. 2015 Oct 19 doi: 10.1055/s-0035-1565273. X-1
3615 Kaiser C. SUFFERING IN SILENCE. JEMS: Journal of Emergency Medical Services. 2015;40(2):30–1 2p. Language: English. Entry Date: 20150213. Revision Date: 20150820. Publication Type: Journal Article. X-1
3616 Kalsched DE. Revisioning Fordham’s ‘Defences of the self’ in light of modern relational theory and contemporary neuroscience. J Anal Psychol. 2015 Sep;60(4):477–96. doi: 10.1111/1468-5922.12165. X-126274848
3617 Kaltiala-Heino R, Sumia M, Tyolajarvi M, . Two years of gender identity service for minors: overrepresentation of natal girls with severe problems in adolescent development. Child Adolesc Psychiatry Ment Health. 2015;9:9. doi: 10.1186/s13034-015-0042-y. X-125873995
3618 Kamio Y, Haraguchi H, Miyake A, . Brief report: large individual variation in outcomes of autistic children receiving low-intensity behavioral interventions in community settings. Child Adolesc Psychiatry Ment Health. 2015;9:6. doi: 10.1186/s13034-015-0039-6. X-425960766
3619 Kamps D, Thiemann-Bourque K, Heitzman-Powell L, . A comprehensive peer network intervention to improve social communication of children with autism spectrum disorders: a randomized trial in kindergarten and first grade. J Autism Dev Disord. 2015 Jun;45(6):1809–24. doi: 10.1007/s10803-014-2340-2. X-125510450
3620 Kanduri C, Kantojarvi K, Salo PM, . The landscape of copy number variations in Finnish families with autism spectrum disorders. Autism Res. 2015 Jun 6 doi: 10.1002/aur.1502. X-1
3621 Kang-Yi CD, Locke J, Marcus SC, . School-Based Behavioral Health Service Use and Expenditures for Children With Autism and Children With Other Disorders. Psychiatr Serv. 2015 Aug 17:appips201400505. doi: 10.1176/appi.ps.201400505. X-1
3622 Kantarcioglu AS, Kiraz N, Aydin A. Microbiota-Gut-Brain Axis: Yeast Species Isolated from Stool Samples of Children with Suspected or Diagnosed Autism Spectrum Disorders and In Vitro Susceptibility Against Nystatin and Fluconazole. Mycopathologia. 2015 Oct 6 doi: 10.1007/s11046-015-9949-3. X-1
3623 Kao YC, Kramer JM, Liljenquist K, . Association between impairment, function, and daily life task management in children and adolescents with autism. Dev Med Child Neurol. 2015 Jan;57(1):68–74. doi: 10.1111/dmcn.12562. X-125312547
3624 Karakurt MN, Suren S. Desmopressin Use in the Treatment of Aripiprazole-Induced Nocturnal Enuresis in a Child Diagnosed with Autistic Disorder. J Child Adolesc Psychopharmacol. 2015 Aug;25(6):518–9. doi: 10.1089/cap.2015.0003. X-3, X-426222623
3625 Karaminis T, Neil L, Manning C, . Ensemble perception of emotions in children with autism. J Vis. 2015 Sep 1;15(12):916. doi: 10.1167/15.12.916. X-1
3626 Karaminis T, Turi M, Neil L, . Atypicalities in perceptual adaptation in autism do not extend to perceptual causality. PLoS One. 2015;10(3):e0120439. doi: 10.1371/journal.pone.0120439. X-125774507
3627 Kardas F, Bayram AK, Demirci E, . Increased Serum Phthalates (MEHP, DEHP) and Bisphenol A Concentrations in Children With Autism Spectrum Disorder: The Role of Endocrine Disruptors in Autism Etiopathogenesis. J Child Neurol. 2015 Oct 8 doi: 10.1177/0883073815609150. X-1
3628 Kargas N, Lopez B, Reddy V, . The relationship between auditory processing and restricted, repetitive behaviors in adults with autism spectrum disorders. J Autism Dev Disord. 2015 Mar;45(3):658–68. doi: 10.1007/s10803-014-2219-2. X-125178987
3629 Karlsson SA, Haziri K, Hansson E, . Effects of sex and gonadectomy on social investigation and social recognition in mice. BMC Neurosci. 2015;16:83. doi: 10.1186/s12868-015-0221-z. X-126608570
3630 Karst JS, Van Hecke AV, Carson AM, . Parent and family outcomes of PEERS: a social skills intervention for adolescents with autism spectrum disorder. J Autism Dev Disord. 2015 Mar;45(3):752–65. doi: 10.1007/s10803-014-2231-6. X-125193142
3631 Karten A, Hirsch J. Brief report: Anomalous neural deactivations and functional connectivity during receptive language in autism spectrum disorder: a functional MRI study. J Autism Dev Disord. 2015 Jun;45(6):1905–14. doi: 10.1007/s10803-014-2344-y. X-125526952
3632 Kasari C. Update on behavioral interventions for autism and developmental disabilities. Curr Opin Neurol. 2015 Apr;28(2):124–9. doi: 10.1097/wco.0000000000000185. X-1, X-225695136
3633 Kasari C, Dean M, Kretzmann M, . Children with autism spectrum disorder and social skills groups at school: a randomized trial comparing intervention approach and peer composition. J Child Psychol Psychiatry. 2015 Sep 22 doi: 10.1111/jcpp.12460. X-1
3634 Kasari C, Gulsrud A, Paparella T, . Randomized comparative efficacy study of parent-mediated interventions for toddlers with autism. J Consult Clin Psychol. 2015 Jun;83(3):554–63. doi: 10.1037/a0039080. X-125822242
3635 Kaslovsky R, Gottsegen D. Hypnosis for Asthma and Vocal Cord Dysfunction in a Patient With Autism. Am J Clin Hypn. 2015;58(2):195–203. doi: 10.1080/00029157.2014.989566. X-1, X-3, X-426264542
3636 Kata SG, Aboumarzouk OM, Zreik A, . Photodynamic diagnostic ureterorenoscopy: A valuable tool in the detection of upper urinary tract tumour. Photodiagnosis Photodyn Ther. 2015 Aug 6 doi: 10.1016/j.pdpdt.2015.08.002. X-1
3637 Katoh M. Mutation spectra of histone methyltransferases with canonical SET domains and EZH2-targeted therapy. Epigenomics. 2015 Sep 28 doi: 10.2217/epi.15.89. X-1
3638 Katz E, Girolametto L. Peer-mediated intervention for pre-schoolers with ASD: Effects on responses and initiations. Int J Speech Lang Pathol. 2015 Apr 17:1–12. doi: 10.3109/17549507.2015.1024166. X-3, X-425539474
3639 Kaur M, Srinivasan SM, Bhat AN. Atypical object exploration in infants at-risk for autism during the first year of lifer. Front Psychol. 2015;6:798. doi: 10.3389/fpsyg.2015.00798. X-126136702
3640 Kaushik G, Thomas MA, Aho KA. Psychoactive pharmaceuticals as environmental contaminants may disrupt highly inter-connected nodes in an Autism-associated protein-protein interaction network. BMC Bioinformatics. 2015;16 Suppl 7:S3. doi: 10.1186/1471-2105-16-s7-s3. X-1
3641 Kazim SF, Cardenas-Aguayo Mdel C, Arif M, . Sera from children with autism induce autistic features which can be rescued with a CNTF small peptide mimetic in rats. PLoS One. 2015;10(3):e0118627. doi: 10.1371/journal.pone.0118627. X-125769033
3642 Keehn B, Vogel-Farley V, Tager-Flusberg H, . Atypical hemispheric specialization for faces in infants at risk for autism spectrum disorder. Autism Res. 2015 Apr;8(2):187–98. doi: 10.1002/aur.1438. X-125808162
3643 Keidan I, Ben-Menachem E, Tzadok M, . Electroencephalography for children with autistic spectrum disorder: a sedation protocol. Paediatr Anaesth. 2015 Feb;25(2):200–5. doi: 10.1111/pan.12510. X-125145661
3644 Kelley ME, Liddon CJ, Ribeiro A, . Basic and translational evaluation of renewal of operant responding. J Appl Behav Anal. 2015 Summer;48(2):390–401. doi: 10.1002/jaba.209. X-125891414
3645 Kelly AM. Caring for Patients with ASD and Their Caregivers: Federal and State Autism-Specific Insurance Reform. AMA J Ethics. 2015 Apr;17(4):328–41. doi: 10.1001/journalofethics.2015.17.4.hlaw1-1504. X-125901701
3646 Kendall W, Kingstone A, Todd R. Detecting emotions is easier in less realistic faces. J Vis. 2015 Sep 1;15(12):1379. doi: 10.1167/15.12.1379. X-1
3647 Kent-Walsh J, Murza KA, Malani MD, . Effects of Communication Partner Instruction on the Communication of Individuals using AAC: A Meta-Analysis. Augment Altern Commun. 2015 Jun 10:1–14. doi: 10.3109/07434618.2015.1052153. X-2
3648 Kerekes N, Tajnia A, Lichtenstein P, . Neurodevelopmental problems and extremes in BMI. PeerJ. 2015;3:e1024. doi: 10.7717/peerj.1024. X-126207189
3649 Kern JK, Geier DA, Sykes LK, . Are ASD and ADHD a Continuum? A Comparison of Pathophysiological Similarities Between the Disorders. J Atten Disord. 2015 Sep;19(9):805–27. doi: 10.1177/1087054712459886. X-123074304
3650 Kerns CM, Maddox BB, Kendall PC, . Brief measures of anxiety in non-treatment-seeking youth with autism spectrum disorder. Autism. 2015 Nov;19(8):969–79. doi: 10.1177/1362361314558465. X-125633222
3651 Kerr EN, Bhan A, Heon E. Exploration of the cognitive, adaptive and behavioral functioning of patients affected with Bardet-Biedl syndrome. Clin Genet. 2015 May 19 doi: 10.1111/cge.12614. X-1
3652 Kestemont J, Ma N, Baetens K, . Neural correlates of attributing causes to the self, another person and the situation. Soc Cogn Affect Neurosci. 2015 Jan;10(1):114–21. doi: 10.1093/scan/nsu030. X-124633532
3653 Kestemont J, Vandekerckhove M, Bulnes LC, . Causal attribution in individuals with subclinical and clinical autism spectrum disorder: An fMRI study. Soc Neurosci. 2015 Aug 11:1–13. doi: 10.1080/17470919.2015.1074104. X-125768232
3654 Khadem A, Hossein-Zadeh GA, Khorrami A. Long-Range Reduced Predictive Information Transfers of Autistic Youths in EEG Sensor-Space During Face Processing. Brain Topogr. 2015 Oct 3 doi: 10.1007/s10548-015-0452-4. X-1
3655 Khaledi N, Arbabi A, Sardari D, . Simultaneous production of mixed electron--photon beam in a medical LINAC: A feasibility study. Phys Med. 2015 Jun;31(4):391–7. doi: 10.1016/j.ejmp.2015.02.014. X-125773884
3656 Khamooshi M, Mirmahdi SR. The effectiveness of sensory integration procedure on reduction of stereotypical behaviors in autistic children. Journal of Iranian Psychologists. 2015 2015–11–25;11(44):417–23; 2015-43162-007. X-5
3657 Khan AJ, Nair A, Keown CL, . Cerebro-cerebellar Resting-State Functional Connectivity in Children and Adolescents with Autism Spectrum Disorder. Biol Psychiatry. 2015 Nov 1;78(9):625–34. doi: 10.1016/j.biopsych.2015.03.024. X-125959247
3658 Khanna R, Jariwala K, West-Strum D. Validity and reliability of the Medical Outcomes Study Short-Form Health Survey version 2 (SF-12v2) among adults with autism. Res Dev Disabil. 2015 Aug–Sep;43–44:51–60. doi: 10.1016/j.ridd.2015.06.006. X-1
3659 Khongrum J, Wattanathorn J. Laser Acupuncture Improves Behavioral Disorders and Brain Oxidative Stress Status in the Valproic Acid Rat Model of Autism. J Acupunct Meridian Stud. 2015 Aug;8(4):183–91. doi: 10.1016/j.jams.2015.06.008. X-126276454
3660 Khowaja K, Salim SS. Heuristics to Evaluate Interactive Systems for Children with Autism Spectrum Disorder (ASD). PLoS One. 2015;10(7):e0132187. doi: 10.1371/journal.pone.0132187. X-1, X-226196385
3661 Kienle X, Freiberger V, Greulich H, . [Autism Spectrum Disorder and DSM-5: Spectrum or Cluster?]. Prax Kinderpsychol Kinderpsychiatr. 2015;64(6):412–28. doi: 10.13109/prkk.2015.64.6.412. X-126289149
3662 Kihara H, Nakamura T. Early standard development assessment characteristics in very low birth weight infants later classified with autism spectrum disorder. Early Hum Dev. 2015 Jun;91(6):357–9. doi: 10.1016/j.earlhumdev.2015.03.012. X-125912387
3663 Kikuchi M, Yoshimura Y, Hiraishi H, . Reduced long-range functional connectivity in young children with autism spectrum disorder. Soc Cogn Affect Neurosci. 2015 Feb;10(2):248–54. doi: 10.1093/scan/nsu049. X-124652855
3664 Kim DJ, Sim MK, Lee SW, . Successful Removal of a Screw Nail in the Jejunum Using Double-Balloon Enteroscopy. Clin Endosc. 2015 Sep;48(5):444–6. doi: 10.5946/ce.2015.48.5.444. X-126473131
3665 Kim SH, Macari S, Koller J, . Examining the phenotypic heterogeneity of early Autism Spectrum Disorder: subtypes and short-term outcomes. J Child Psychol Psychiatry. 2015 Aug 12 doi: 10.1111/jcpp.12448. X-1
3666 Kim SN, Jo GH, Kim HA, . Aberrant IgG isotype generation in mice with abnormal behaviors. J Immunotoxicol. 2015 Feb 18:1–5. doi: 10.3109/1547691x.2015.1014581. X-1
3667 Kim SY, Choi US, Park SY, . Abnormal activation of the social brain network in children with autism spectrum disorder: an FMRI study. Psychiatry Investig. 2015 Jan;12(1):37–45. doi: 10.4306/pi.2015.12.1.37. X-1
3668 Kim YJ, Park JK, Kang WS, . LAMB1 polymorphism is associated with autism symptom severity in Korean autism spectrum disorder patients. Nord J Psychiatry. 2015 Nov;69(8):594–8. doi: 10.3109/08039488.2015.1022597. X-125774865
3669 Kirby AV, Little LM, Schultz B, . Observational Characterization of Sensory Interests, Repetitions, and Seeking Behaviors. American Journal of Occupational Therapy. 2015;69(3):p1–9 1p. doi: 10.5014/ajot.2015.015081. Language: English. Entry Date: 20150505. Revision Date: 20150819. Publication Type: Journal Article. X-1
3670 Kirby AV, White TJ, Baranek GT. Caregiver strain and sensory features in children with autism spectrum disorder and other developmental disabilities. Am J Intellect Dev Disabil. 2015 Jan;120(1):32–45. doi: 10.1352/1944-7558-120.1.32. X-125551265
3671 Kirsten TB, Chaves-Kirsten GP, Bernardes S, . Lipopolysaccharide Exposure Induces Maternal Hypozincemia, and Prenatal Zinc Treatment Prevents Autistic-Like Behaviors and Disturbances in the Striatal Dopaminergic and mTOR Systems of Offspring. PLoS One. 2015;10(7):e0134565. doi: 10.1371/journal.pone.0134565. X-126218250
3672 Kirsten TB, Queiroz-Hazarbassanov N, Bernardi MM, . Prenatal zinc prevents communication impairments and BDNF disturbance in a rat model of autism induced by prenatal lipopolysaccharide exposure. Life Sci. 2015 Jun 1;130:12–7. doi: 10.1016/j.lfs.2015.02.027. X-125817235
3673 Kissin DM, Zhang Y, Boulet SL, . Association of assisted reproductive technology (ART) treatment and parental infertility diagnosis with autism in ART-conceived children. Hum Reprod. 2015 Feb;30(2):454–65. doi: 10.1093/humrep/deu338. X-125518976
3674 Kleberg JL, Selbing I, Lundqvist D, . Spontaneous eye movements and trait empathy predict vicarious learning of fear. Int J Psychophysiol. 2015 Apr 11 doi: 10.1016/j.ijpsycho.2015.04.001. X-1
3675 Kleiman GH, Barnea A, Gozes I. ADNP: A major autism mutated gene is differentially distributed (age and gender) in the songbird brain. Peptides. 2015 Apr 17 doi: 10.1016/j.peptides.2015.04.008. X-1
3676 Kleinhans NM, Reiter MA, Neuhaus E, . Subregional differences in intrinsic amygdala hyperconnectivity and hypoconnectivity in autism spectrum disorder. Autism Res. 2015 Dec 15 doi: 10.1002/aur.1589. X-1
3677 Klin A, Klaiman C, Jones W. Reducing age of autism diagnosis: developmental social neuroscience meets public health challenge. Rev Neurol. 2015 Feb 25;60 Suppl 1:S3–11. X-125726820
3678 Klintwall L, Eldevik S, Eikeseth S. Narrowing the gap: effects of intervention on developmental trajectories in autism. Autism. 2015 Jan;19(1):53–63. doi: 10.1177/1362361313510067. X-1, X-224212258
3679 Klintwall L, Macari S, Eikeseth S, . Interest level in 2-year-olds with autism spectrum disorder predicts rate of verbal, nonverbal, and adaptive skill acquisition. Autism. 2015 Nov;19(8):925–33. doi: 10.1177/1362361314555376. X-125398893
3680 Klukowski M, Wasilewska J, Lebensztejn D. Smith-Magenis syndrome and its circadian influence on development, behavior, and obesity - own experience. Dev Period Med. 2015 Apr–Jun;19(2):157–61. X-126384115
3681 Klusek J, Roberts JE, Losh M. Cardiac autonomic regulation in autism and Fragile X syndrome: a review. Psychol Bull. 2015 Jan;141(1):141–75. doi: 10.1037/a0038237. X-1, X-225420222
3682 Knutsen J, Mandell DS, Frye D. Children with autism are impaired in the understanding of teaching. Dev Sci. 2015 Dec 8 doi: 10.1111/desc.12368. X-1
3683 Ko WR, Huang JY, Chiang YC, . Risk of autistic disorder after exposure to general anaesthesia and surgery: a nationwide, retrospective matched cohort study. Eur J Anaesthesiol. 2015 May;32(5):303–10. doi: 10.1097/eja.0000000000000130. X-125101714
3684 Kobayashi T, Hirano Y, Nemoto K, . Correlation between Morphologic Changes and Autism Spectrum Tendency in Obsessive-Compulsive Disorder. Magn Reson Med Sci. 2015 Jun 23 doi: 10.2463/mrms.2014-0146. X-1
3685 Kobeissy F, Moshourab RA. Frontiers in Neuroengineering Autoantibodies in CNS Trauma and Neuropsychiatric Disorders: A New Generation of Biomarkers. In: Kobeissy FH, ed Brain Neurotrauma: Molecular, Neuropsychological, and Rehabilitation Aspects. Boca Raton (FL): CRC Press (c) 2015 by Taylor & Francis Group, LLC.; 2015.
3686 Koch SC, Mehl L, Sobanski E, . Fixing the mirrors: a feasibility study of the effects of dance movement therapy on young adults with autism spectrum disorder. Autism. 2015 Apr;19(3):338–50. doi: 10.1177/1362361314522353. X-124566716
3687 Kodak T, Clements A, Paden AR, . Examination of the relation between an assessment of skills and performance on auditory-visual conditional discriminations for children with autism spectrum disorder. J Appl Behav Anal. 2015 Spring;48(1):52–70. doi: 10.1002/jaba.160. X-125293383
3688 Kosmicki JA, Sochat V, Duda M, . Searching for a minimal set of behaviors for autism detection through feature selection-based machine learning. Transl Psychiatry. 2015;5:e514. doi: 10.1038/tp.2015.7. X-125710120
3689 Kovelman I, Wagley N, Hay JS, . Multimodal imaging of temporal processing in typical and atypical language development. Ann N Y Acad Sci. 2015 Mar;1337:7–15. doi: 10.1111/nyas.12688. X-125773611
3690 Kovtun O, Sakrikar D, Tomlinson ID, . Single-quantum-dot tracking reveals altered membrane dynamics of an attention-deficit/hyperactivity-disorder-derived dopamine transporter coding variant. ACS Chem Neurosci. 2015 Apr 15;6(4):526–34. doi: 10.1021/cn500202c. X-125747272
3691 Krakowiak P, Goines PE, Tancredi DJ, . Neonatal Cytokine Profiles Associated with Autism Spectrum Disorder. Biol Psychiatry. 2015 Aug 14 doi: 10.1016/j.biopsych.2015.08.007. X-1
3692 Krakowiak P, Walker CK, Tancredi DJ, . Maternal Recall Versus Medical Records of Metabolic Conditions from the Prenatal Period: A Validation Study. Matern Child Health J. 2015 Sep;19(9):1925–35. doi: 10.1007/s10995-015-1723-0. X-125656730
3693 Kral TV, Souders MC, Tompkins VH, . Child Eating Behaviors and Caregiver Feeding Practices in Children with Autism Spectrum Disorders. Public Health Nurs. 2015 Sep;32(5):488–97. doi: 10.1111/phn.12146. X-125112438
3694 Kramer JM, Liljenquist K, Ni P, . Examining differential responses of youth with and without autism on a measure of everyday activity performance. Qual Life Res. 2015 Dec;24(12):2993–3000. doi: 10.1007/s11136-015-1035-2. X-126063170
3695 Kreibich SR, Chen M, Reichle J. Teaching a Child With Autism to Request Breaks While Concurrently Increasing Task Engagement. Lang Speech Hear Serv Sch. 2015 Jul;46(3):256–65. doi: 10.1044/2015_lshss-14-0081. X-3, X-425908538
3696 Kreslins A, Robertson AE, Melville C. The effectiveness of psychosocial interventions for anxiety in children and adolescents with autism spectrum disorder: a systematic review and meta-analysis. Child Adolesc Psychiatry Ment Health. 2015;9:22. doi: 10.1186/s13034-015-0054-7. X-226120361
3697 Krigbaum G, Wigton NL. A Methodology of Analysis for Monitoring Treatment Progression with 19-Channel Z-Score Neurofeedback (19ZNF) in a Single-Subject Design. Appl Psychophysiol Biofeedback. 2015 Sep;40(3):139–49. doi: 10.1007/s10484-015-9274-0. X-125777656
3698 Kronenberg LM, Goossens PJ, van Busschbach J, . Coping styles in substance use disorder (SUD) patients with and without co-occurring attention deficit/hyperactivity disorder (ADHD) or autism spectrum disorder (ASD). BMC Psychiatry. 2015;15:159. doi: 10.1186/s12888-015-0530-x. X-126169586
3699 Kryzak LA, Cengher M, Feeley KM, . A community support program for children with autism and their typically developing siblings: Initial investigation. J Intellect Disabil. 2015 Jun;19(2):159–77. doi: 10.1177/1744629514564450. X-125542700
3700 Kubota T, Miyake K, Hariya N, . Epigenomic-basis of Preemptive Medicine for Neurodevelopmental Disorders. Curr Genomics. 2015 Jun;16(3):175–82. doi: 10.2174/1389202916666150216221312. X-126069457
3701 Kuhaneck HM, Madonna S, Novak A, . Effectiveness of Interventions for Children With Autism Spectrum Disorder and Their Parents: A Systematic Review of Family Outcomes. Am J Occup Ther. 2015 Sep–Oct;69(5):6905180040p1–p14. doi: 10.5014/ajot.2015.017855. X-2, X-3
3702 Kuhaneck HM, Watling R. Occupational Therapy: Meeting the Needs of Families of People With Autism Spectrum Disorder. Am J Occup Ther. 2015 Sep–Oct;69(5):6905170010p1–5. doi: 10.5014/ajot.2015.019562. X-1, X-2
3703 Kuhlthau KA, Warfield ME, Hurson J, . Pediatric provider’s perspectives on the transition to adult health care for youth with autism spectrum disorder: current strategies and promising new directions. Autism. 2015 Apr;19(3):262–71. doi: 10.1177/1362361313518125. X-124497626
3704 Kumar H, Sharma BM, Sharma B. Benefits of agomelatine in behavioral, neurochemical and blood brain barrier alterations in prenatal valproic acid induced autism spectrum disorder. Neurochem Int. 2015 Oct 20 doi: 10.1016/j.neuint.2015.10.007. X-1
3705 Kumar R, Pallagatti S, Sheikh S, . Correlation Between Clinical Findings of Temporomandibular Disorders and MRI Characteristics of Disc Displacement. Open Dent J. 2015;9:273–81. doi: 10.2174/1874210601509010273. X-126464595
3706 Kuo N-C, Plavnick JB. Using an Antecedent Art Intervention to Improve the Behavior of a Child With Autism. Art Therapy: Journal of the American Art Therapy Association. 2015;32(2):54–9 6p. doi: 10.1080/07421656.2015.1028312. Language: English. Entry Date: 20150730. Revision Date: 20150923. Publication Type: Journal Article. X-1, X-3, X-4
3707 Kuriakose S, Lahiri U. Understanding the Psycho-Physiological Implications of Interaction With a Virtual Reality-Based System in Adolescents With Autism: A Feasibility Study. IEEE Trans Neural Syst Rehabil Eng. 2015 Jul;23(4):665–75. doi: 10.1109/tnsre.2015.2393891. X-125643409
3708 Kurtz PF, Chin MD, Robinson AN, . Functional analysis and treatment of problem behavior exhibited by children with fragile X syndrome. Res Dev Disabil. 2015 Aug–Sep;43–44:150–66. doi: 10.1016/j.ridd.2015.06.010. X-1
3709 Kuschner ES, Eisenberg IW, Orionzi B, . A Preliminary Study of Self-Reported Food Selectivity in Adolescents and Young Adults with Autism Spectrum Disorder. Res Autism Spectr Disord. 2015 Jul 1;15–16:53–9. doi: 10.1016/j.rasd.2015.04.005. X-1
3710 Kushki A, Khan A, Brian J, . A Kalman filtering framework for physiological detection of anxiety-related arousal in children with autism spectrum disorder. IEEE Trans Biomed Eng. 2015 Mar;62(3):990–1000. doi: 10.1109/tbme.2014.2377555. X-125494497
3711 Kwon KJ, Lee EJ, Kim MK, . The potential role of melatonin on sleep deprivation-induced cognitive impairments: implication of FMRP on cognitive function. Neuroscience. 2015 Aug 20;301:403–14. doi: 10.1016/j.neuroscience.2015.05.079. X-126047724
3712 Kyzar EJ, Stewart AM, Kalueff AV. Effects of LSD on grooming behavior in serotonin transporter heterozygous (Sert) mice. Behav Brain Res. 2015 Sep 1;296:47–52. doi: 10.1016/j.bbr.2015.08.018. X-126340513
3713 LaFrance DL, Miguel CF, Donahue JN, . A case study on the use of auditory integration training as a treatment for stereotypy. Behavioral Interventions. 2015 2015-12-09;30(3):286–93. doi: http://dx.doi.org/10.1002/bin.1415; 2015-27676-001. X-1
3714 Laghi F, Federico F, Lonigro A, . Peer and Teacher-Selected Peer Buddies for Adolescents With Autism Spectrum Disorders: The Role of Social, Emotional, and Mentalizing Abilities. J Psychol. 2015 Sep 23:1–22. doi: 10.1080/00223980.2015.1087375. X-1
3715 Lahiri U, Bekele E, Dohrmann E, . A physiologically informed virtual reality based social communication system for individuals with autism. J Autism Dev Disord. 2015 Apr;45(4):919–31. doi: 10.1007/s10803-014-2240-5. X-125261247
3716 Lai WW, Goh TJ, Oei TP, . Coping and Well-Being in Parents of Children with Autism Spectrum Disorders (ASD). J Autism Dev Disord. 2015 Aug;45(8):2582–93. doi: 10.1007/s10803-015-2430-9. X-125800867
3717 Lake JK, Vogan V, Sawyer A, . Psychotropic medication use among adolescents and young adults with an autism spectrum disorder: parent views about medication use and healthcare services. J Child Adolesc Psychopharmacol. 2015 Apr;25(3):260–8. doi: 10.1089/cap.2014.0106. X-125803636
3718 Lal D, Pernhorst K, Klein KM, . Extending the phenotypic spectrum of RBFOX1 deletions: Sporadic focal epilepsy. Epilepsia. 2015 Sep;56(9):e129–e33. doi: 10.1111/epi.13076. X-126174448
3719 Lal D, Ruppert AK, Trucks H, . Burden analysis of rare microdeletions suggests a strong impact of neurodevelopmental genes in genetic generalised epilepsies. PLoS Genet. 2015 May;11(5):e1005226. doi: 10.1371/journal.pgen.1005226. X-125950944
3720 Lalanne L, Weiner L, Trojak B, . Substance-use disorder in high-functioning autism: clinical and neurocognitive insights from two case reports. BMC Psychiatry. 2015;15:149. doi: 10.1186/s12888-015-0541-7. X-126149411
3721 Landy KM, Salmon DP, Filoteo JV, . Visual search in Dementia with Lewy Bodies and Alzheimer’s disease. Cortex. 2015 Sep 21;73:228–39. doi: 10.1016/j.cortex.2015.08.020. X-126476402
3722 Lane R, Kessler R, Buckley AW, . Evaluation of Periodic Limb Movements in Sleep and Iron Status in Children With Autism. Pediatr Neurol. 2015 Oct;53(4):343–9. doi: 10.1016/j.pediatrneurol.2015.06.014. X-126231264
3723 Lange KW, Hauser J, Reissmann A. Gluten-free and casein-free diets in the therapy of autism. Curr Opin Clin Nutr Metab Care. 2015 Nov;18(6):572–5. doi: 10.1097/mco.0000000000000228. X-1, X-326418822
3724 Lange N, Travers BG, Bigler ED, . Longitudinal volumetric brain changes in autism spectrum disorder ages 6–35 years. Autism Res. 2015 Feb;8(1):82–93. doi: 10.1002/aur.1427. X-125381736
3725 Langley EA, Krykbaeva M, Blusztajn JK, . High maternal choline consumption during pregnancy and nursing alleviates deficits in social interaction and improves anxiety-like behaviors in the BTBR T+Itpr3tf/J mouse model of autism. Behav Brain Res. 2015 Feb 1;278:210–20. doi: 10.1016/j.bbr.2014.09.043. X-125300468
3726 Lanovaz MJ, Dufour MM, Shah S. Newspaper Coverage of Autism Treatment in Canada: 10-Year Trends (2004–2013). Can J Psychiatry. 2015 Jul;60(7):329–33. X-1, X-226175392
3727 Lanovaz MJ, Rapp JT, Maciw I, . Preliminary effects of parent-implemented behavioural interventions for stereotypy: Brief report. Dev Neurorehabil. 2015 Aug 24:1–4. doi: 10.3109/17518423.2014.986821. X-3, X-4
3728 Larson FV, Lai MC, Wagner AP, . Testing the ‘Extreme Female Brain’ Theory of Psychosis in Adults with Autism Spectrum Disorder with or without Co-Morbid Psychosis. PLoS One. 2015;10(6):e0128102. doi: 10.1371/journal.pone.0128102. X-126069955
3729 Laue CL. CONSIDERING THE EFFECTS OF GENDER IN CHILD-ROBOT INTERACTION STUDIES: COMMENT ON SRINIVASAN, ET AL. ( 2013. Perceptual & Motor Skills. 2015;120(1):336–42 7p. doi: 10.2466/15.10.PMS.120v16x4. Language: English. Entry Date: 20150227. Revision Date: 20150710. Publication Type: Journal Article. X-1, X-225668075
3730 Laugeson EA, Gantman A, Kapp SK, . A Randomized Controlled Trial to Improve Social Skills in Young Adults with Autism Spectrum Disorder: The UCLA PEERS Program. J Autism Dev Disord. 2015 Jun 25 doi: 10.1007/s10803-015-2504-8. X-1
3731 Laugeson EA, Gantman A, Kapp SK, . A Randomized Controlled Trial to Improve Social Skills in Young Adults with Autism Spectrum Disorder: The UCLA PEERS((R)) Program. J Autism Dev Disord. 2015 Dec;45(12):3978–89. doi: 10.1007/s10803-015-2504-8. X-126109247
3732 Lawson RA, Papadakis AA, Higginson CI, . Everyday executive function impairments predict comorbid psychopathology in autism spectrum and attention deficit hyperactivity disorders. Neuropsychology. 2015 May;29(3):445–53. doi: 10.1037/neu0000145. X-125313979
3733 Laxman DJ, McBride BA, Jeans LM, . Father involvement and maternal depressive symptoms in families of children with disabilities or delays. Matern Child Health J. 2015 May;19(5):1078–86. doi: 10.1007/s10995-014-1608-7. X-125326111
3734 Leaf JB, Leaf R, McEachin J, . Applied Behavior Analysis is a Science and, Therefore, Progressive. J Autism Dev Disord. 2015 Sep 15 doi: 10.1007/s10803-015-2591-6. X-1
3735 LeBarton ES, Iverson JM. Gesture development in toddlers with an older sibling with autism. Int J Lang Commun Disord. 2015 Sep 6 doi: 10.1111/1460-6984.12180. X-1
3736 Lechpammer M, Wintermark P, Merry KM, . Dysregulation of FMRP/mTOR Signaling Cascade in Hypoxic-Ischemic Injury of Premature Human Brain. J Child Neurol. 2015 Aug 3 doi: 10.1177/0883073815596617. X-1
3737 LeClerc S, Easley D. Pharmacological therapies for autism spectrum disorder: a review. P t. 2015 Jun;40(6):389–97. X-226045648
3738 Ledbetter-Cho K, Lang R, Davenport K, . Effects of script training on the peer-to-peer communication of children with autism spectrum disorder. J Appl Behav Anal. 2015 Aug 24 doi: 10.1002/jaba.240. X-3, X-4
3739 Ledford JR, Wehby JH. Teaching Children with Autism in Small Groups with Students Who are At-Risk for Academic Problems: Effects on Academic and Social Behaviors. J Autism Dev Disord. 2015 Jun;45(6):1624–35. doi: 10.1007/s10803-014-2317-1. X-1, X-325409705
3740 Lee A, Lang R, Davenport K, . Comparison of therapist implemented and iPad-assisted interventions for children with autism. Dev Neurorehabil. 2015 Apr;18(2):97–103. doi: 10.3109/17518423.2013.830231. X-3, X-424088050
3741 Lee BK, Magnusson C, Gardner RM, . Maternal hospitalization with infection during pregnancy and risk of autism spectrum disorders. Brain Behav Immun. 2015 Feb;44:100–5. doi: 10.1016/j.bbi.2014.09.001. X-125218900
3742 Lee IS, Carvalho CM, Douvaras P, . Characterization of molecular and cellular phenotypes associated with a heterozygous CNTNAP2 deletion using patient-derived hiPSC neural cells. NPJ Schizophr. 2015 Jun 24;1. X-1
3743 Lee JY, Cho KS, Kang DH, . A network meta-analysis of therapeutic outcomes after new image technology-assisted transurethral resection for non-muscle invasive bladder cancer: 5-aminolaevulinic acid fluorescence vs hexylaminolevulinate fluorescence vs narrow band imaging. BMC Cancer. 2015;15:566. doi: 10.1186/s12885-015-1571-8. X-126232037
3744 Lee KM, Chiu KB, Didier PJ, . Naltrexone treatment reverses astrocyte atrophy and immune dysfunction in self-harming macaques. Brain Behav Immun. 2015 Jul 17 doi: 10.1016/j.bbi.2015.07.017. X-1
3745 Lee SB, Song SH, Ham JH, . Idiom Comprehension Deficits in High-Functioning Autism Spectrum Disorder Using a Korean Autism Social Language Task. Yonsei Med J. 2015 Nov;56(6):1613–8. doi: 10.3349/ymj.2015.56.6.1613. X-126446644
3746 Lefebvre A, Beggiato A, Bourgeron T, . Neuroanatomical Diversity of Corpus Callosum and Brain Volume in Autism: Meta-analysis, Analysis of the Autism Brain Imaging Data Exchange Project, and Simulation. Biol Psychiatry. 2015 Jul 15;78(2):126–34. doi: 10.1016/j.biopsych.2015.02.010. X-125850620
3747 Lefort R. Reversing synapse loss in Alzheimer’s disease: Rho-guanosine triphosphatases and insights from other brain disorders. Neurotherapeutics. 2015 Jan;12(1):19–28. doi: 10.1007/s13311-014-0328-4. X-125588580
3748 Lerman DC, Hawkins L, Hillman C, . Adults with autism spectrum disorder as behavior technicians for young children with autism: Outcomes of a behavioral skills training program. J Appl Behav Anal. 2015 Summer;48(2):233–56. doi: 10.1002/jaba.196. X-1, X-3, X-425869079
3749 Lerthattasilp T, Charernboon T, Chunsuwan I, . Depression and burden among caregivers of children with autistic spectrum disorder. J Med Assoc Thai. 2015 Mar;98 Suppl 2:S45–52. X-1
3750 Leung RC, Vogan VM, Powell TL, . The role of executive functions in social impairment in Autism Spectrum Disorder. Child Neuropsychol. 2015 Mar 3:1–9. doi: 10.1080/09297049.2015.1005066. X-1
3751 Levin AR, Fox NA, Zeanah CH, Jr., . Social communication difficulties and autism in previously institutionalized children. J Am Acad Child Adolesc Psychiatry. 2015 Feb;54(2):108–15.e1. doi: 10.1016/j.jaac.2014.11.011. X-125617251
3752 Levin IP, Gaeth GJ, Foley-Nicpon M, . Extending decision making competence to special populations: a pilot study of persons on the autism spectrum. Front Psychol. 2015;6:539. doi: 10.3389/fpsyg.2015.00539. X-125972831
3753 Li HH, Shan L, Du L, . [Research advances in the management of autism spectrum disorders in children]. Zhongguo Dang Dai Er Ke Za Zhi. 2015 Aug;17(8):886–92. X-1, X-226287360
3754 Li J, Cai T, Jiang Y, . Genes with de novo mutations are shared by four neuropsychiatric disorders discovered from NPdenovo database. Mol Psychiatry. 2015 Apr 7 doi: 10.1038/mp.2015.40. X-1
3755 Li Q, Chen CF, Wang DY, . Transplantation of umbilical cord blood mononuclear cells increases levels of nerve growth factor in the cerebrospinal fluid of patients with autism. Genet Mol Res. 2015;14(3):8725–32. doi: 10.4238/2015.July.31.21. X-126345804
3756 Li YM, Ou JJ, Liu L, . Association Between Maternal Obesity and Autism Spectrum Disorder in Offspring: A Meta-analysis. J Autism Dev Disord. 2015 Aug 9 doi: 10.1007/s10803-015-2549-8. X-1
3757 Li Z, Yu Z, Zhang J, . Impact of Rivastigmine on Cognitive Dysfunction and Falling in Parkinson’s Disease Patients. Eur Neurol. 2015;74(1–2):86–91. doi: 10.1159/000438824. X-126288230
3758 Lichtman JS, Sonnenburg JL, Elias JE. Monitoring host responses to the gut microbiota. Isme j. 2015 Sep;9(9):1908–15. doi: 10.1038/ismej.2015.93. X-126057846
3759 Light J, McNaughton D. Designing AAC Research and Intervention to Improve Outcomes for Individuals with Complex Communication Needs. Augment Altern Commun. 2015 Jun;31(2):85–96. doi: 10.3109/07434618.2015.1036458. X-125904008
3760 Lim CK, Essa MM, de Paula Martins R, . Altered kynurenine pathway metabolism in autism: Implication for immune-induced glutamatergic activity. Autism Res. 2015 Oct 24 doi: 10.1002/aur.1565. X-1
3761 Lim CM. Accommodating Autistics and Treating Autism: Can We Have Both? Bioethics. 2015 Oct;29(8):564–72. doi: 10.1111/bioe.12154. X-1, X-225689416
3762 Lim L, Chantiluke K, Cubillo AI, . Disorder-specific grey matter deficits in attention deficit hyperactivity disorder relative to autism spectrum disorder. Psychol Med. 2015 Apr;45(5):965–76. doi: 10.1017/s0033291714001974. X-125229248
3763 Lin IF, Mochida T, Asada K, . Atypical delayed auditory feedback effect and Lombard effect on speech production in high-functioning adults with autism spectrum disorder. Front Hum Neurosci. 2015;9:510. doi: 10.3389/fnhum.2015.00510. X-126441607
3764 Lin IF, Yamada T, Komine Y, . Enhanced segregation of concurrent sounds with similar spectral uncertainties in individuals with autism spectrum disorder. Sci Rep. 2015;5:10524. doi: 10.1038/srep10524. X-126001110
3765 Lin IF, Yamada T, Komine Y, . Vocal Identity Recognition in Autism Spectrum Disorder. PLoS One. 2015;10(6):e0129451. doi: 10.1371/journal.pone.0129451. X-126070199
3766 Lindberg D, Shan D, Ayers-Ringler J, . Purinergic signaling and energy homeostasis in psychiatric disorders. Curr Mol Med. 2015;15(3):275–95. X-125950756
3767 Lindly OJ, Sinche BK, Zuckerman KE. Variation in Educational Services Receipt Among US Children With Developmental Conditions. Acad Pediatr. 2015 Sep–Oct;15(5):534–43. doi: 10.1016/j.acap.2015.04.001. X-126344719
3768 Lisiecka DM, Holt R, Tait R, . Developmental white matter microstructure in autism phenotype and corresponding endophenotype during adolescence. Transl Psychiatry. 2015;5:e529. doi: 10.1038/tp.2015.23. X-125781228
3769 Little LM, Ausderau K, Sideris J, . Activity Participation and Sensory Features Among Children with Autism Spectrum Disorders. J Autism Dev Disord. 2015 Sep;45(9):2981–90. doi: 10.1007/s10803-015-2460-3. X-125975628
3770 Littlewood RA, Claus ED, Arenella P, . Dose specific effects of olanzapine in the treatment of alcohol dependence. Psychopharmacology (Berl). 2015 Apr;232(7):1261–8. doi: 10.1007/s00213-014-3757-1. X-125304864
3771 Liu X, Kawashima M, Miyagawa T, . Novel rare variations of the oxytocin receptor (OXTR) gene in autism spectrum disorder individuals. Hum Genome Var. 2015;2:15024. doi: 10.1038/hgv.2015.24. X-127081536
3772 Liu Z, Qian Y, Zhang Y, . Effects of several temporomandibular disorders on the stress distributions of temporomandibular joint: a finite element analysis. Comput Methods Biomech Biomed Engin. 2015 Jan 14:1–7. doi: 10.1080/10255842.2014.996876. X-1
3773 Llorens F, Schmitz M, Gloeckner SF, . Increased albumin CSF/serum ratio in dementia with Lewy bodies. J Neurol Sci. 2015 Oct 14 doi: 10.1016/j.jns.2015.10.011. X-1
3774 Lloyd BP, Finley CI, Weaver ES. Experimental analysis of stereotypy with applications of nonparametric statistical tests for alternating treatments designs. Dev Neurorehabil. 2015 Nov 17:1–11. doi: 10.3109/17518423.2015.1091043. X-1
3775 Loades ME. Evidence-Based Practice in the Face of Complexity and Comorbidity: A Case Study of an Adolescent With Asperger’s Syndrome, Anxiety, Depression, and Chronic Pain. J Child Adolesc Psychiatr Nurs. 2015 May;28(2):73–83. doi: 10.1111/jcap.12108. X-1, X-3, X-425865961
3776 Locke J, Olsen A, Wideman R, . A tangled web: the challenges of implementing an evidence-based social engagement intervention for children with autism in urban public school settings. Behav Ther. 2015 Jan;46(1):54–67. doi: 10.1016/j.beth.2014.05.001. X-1, X-3, X-425526835
3777 Locke J, Shih W, Kretzmann M, . Examining playground engagement between elementary school children with and without autism spectrum disorder. Autism. 2015 Sep 4 doi: 10.1177/1362361315599468. X-1
3778 Logan SL, Carpenter L, Leslie RS, . Aberrant Behaviors and Co-occurring Conditions as Predictors of Psychotropic Polypharmacy among Children with Autism Spectrum Disorders. J Child Adolesc Psychopharmacol. 2015 May;25(4):323–36. doi: 10.1089/cap.2013.0119. X-125919445
3779 Lotan Y. Promises and challenges of fluorescence cystoscopy. Urol Oncol. 2015 Jun;33(6):261–4. doi: 10.1016/j.urolonc.2015.03.019. X-125937623
3780 Lough E, Hanley M, Rodgers J, . Violations of Personal Space in Young People with Autism Spectrum Disorders and Williams Syndrome: Insights from the Social Responsiveness Scale. J Autism Dev Disord. 2015 Jul 24 doi: 10.1007/s10803-015-2536-0. X-1
3781 Loukas KM, Raymond L, Perron AR, . Occupational transformation: Parental influence and social cognition of young adults with autism. Work. 2015;50(3):457–63. doi: 10.3233/wor-141956. X-125248535
3782 Louw JJ, Corveleyn A, Jia Y, . MEIS2 involvement in cardiac development, cleft palate, and intellectual disability. Am J Med Genet A. 2015 May;167a(5):1142–6. doi: 10.1002/ajmg.a.36989. X-125712757
3783 Lozano R, Martinez-Cerdeno V, Hagerman RJ. Advances In The Understanding Of The Gabaergic Neurobiology Of Fmr1 Expanded Alleles Leading To Targeted Treatments For Fragile X Spectrum Disorder. Curr Pharm Des. 2015 Sep 14. X-1
3784 Lugnegard T, Hallerback MU, Gillberg C. Asperger syndrome and schizophrenia: Overlap of self-reported autistic traits using the Autism-spectrum Quotient (AQ). Nord J Psychiatry. 2015 May;69(4):268–74. doi: 10.3109/08039488.2014.972452. X-125389915
3785 Lukas M, Wohr M. Endogenous vasopressin, innate anxiety, and the emission of pro-social 50-kHz ultrasonic vocalizations during social play behavior in juvenile rats. Psychoneuroendocrinology. 2015 Jun;56:35–44. doi: 10.1016/j.psyneuen.2015.03.005. X-125800147
3786 Lukic A, Uphill J, Brown CA, . Rare structural genetic variation in human prion diseases. Neurobiol Aging. 2015 May;36(5):2004.e1–8. doi: 10.1016/j.neurobiolaging.2015.01.011. X-1
3787 Lumu L, Albertyn L, Szabo CP. Psychiatric services for preschoolers: an emerging need. J Child Adolesc Ment Health. 2015 Jul;27(2):113–24. doi: 10.2989/17280583.2015.1081207. X-126357917
3788 Lundstrom S, Reichenberg A, Melke J, . Autism spectrum disorders and coexisting disorders in a nationwide Swedish twin study. J Child Psychol Psychiatry. 2015 Jun;56(6):702–10. doi: 10.1111/jcpp.12329. X-125279993
3789 Lyall K, Van de Water J, Ashwood P, . Asthma and Allergies in Children With Autism Spectrum Disorders: Results From the CHARGE Study. Autism Res. 2015 Oct;8(5):567–74. doi: 10.1002/aur.1471. X-125722050
3790 Lydon S, Healy O, Reed P, . A systematic review of physiological reactivity to stimuli in autism. Dev Neurorehabil. 2015 Aug 24:1–21. doi: 10.3109/17518423.2014.971975. X-1, X-2
3791 Lynch BA, Weaver AL, Starr SR, . Developmental Screening and Follow-up by Nurses. MCN Am J Matern Child Nurs. 2015 Nov–Dec;40(6):388–93. doi: 10.1097/nmc.0000000000000179. X-126488856
3792 Ma L, Fu C, Liu H, . [Retrospective study of the efficacy and safety of treatment with PDD vs PAD in de novo patients with multiple myiloma]. Zhonghua Xue Ye Xue Za Zhi. 2015 Apr;36(4):340–3. doi: 10.3760/cma.j.issn.0253-2727.2015.04.018. X-125916300
3793 Ma YH, Li YW, Ma L, . Anesthesia for stem cell transplantation in autistic children: A prospective, randomized, double-blind comparison of propofol and etomidate following sevoflurane inhalation. Exp Ther Med. 2015 Mar;9(3):1035–9. doi: 10.3892/etm.2015.2176. X-125667673
3794 MacFabe DF. Enteric short-chain fatty acids: microbial messengers of metabolism, mitochondria, and mind: implications in autism spectrum disorders. Microb Ecol Health Dis. 2015;26:28177. doi: 10.3402/mehd.v26.28177. X-126031685
3795 Machado C, Estevez M, Leisman G, . QEEG spectral and coherence assessment of autistic children in three different experimental conditions. J Autism Dev Disord. 2015 Feb;45(2):406–24. doi: 10.1007/s10803-013-1909-5. X-1, X-324048514
3796 Machado CJ, Whitaker AM, Smith SE, . Maternal immune activation in nonhuman primates alters social attention in juvenile offspring. Biol Psychiatry. 2015 May 1;77(9):823–32. doi: 10.1016/j.biopsych.2014.07.035. X-125442006
3797 MacMullin JA, Lunsky Y, Weiss JA. Plugged in: Electronics use in youth and young adults with autism spectrum disorder. Autism. 2015 Feb 18 doi: 10.1177/1362361314566047. X-1
3798 Madsen GF, Bilenberg N, Jepsen JR, . Normal P50 Gating in Children with Autism, Yet Attenuated P50 Amplitude in the Asperger Subcategory. Autism Res. 2015 Aug;8(4):371–8. doi: 10.1002/aur.1452. X-125599888
3799 Maekawa M, Iwayama Y, Ohnishi T, . Investigation of the fatty acid transporter-encoding genes SLC27A3 and SLC27A4 in autism. Sci Rep. 2015;5:16239. doi: 10.1038/srep16239. X-126548558
3800 Magana S, Lopez K, Machalicek W. Parents Taking Action: A Psycho-Educational Intervention for Latino Parents of Children With Autism Spectrum Disorder. Fam Process. 2015 Aug 13 doi: 10.1111/famp.12169. X-3, X-4
3801 Magana S, Parish SL, Son E. Have Racial and Ethnic Disparities in the Quality of Health Care Relationships Changed for Children With Developmental Disabilities and ASD? Am J Intellect Dev Disabil. 2015 Nov;120(6):504–13. doi: 10.1352/1944-7558-120.6.504. X-126505871
3802 Magiati I, Ong C, Lim XY, . Anxiety symptoms in young people with autism spectrum disorder attending special schools: Associations with gender, adaptive functioning and autism symptomatology. Autism. 2015 Apr 27 doi: 10.1177/1362361315577519. X-1
3803 Magid-Bernstein J, Mahajan K, Lincoln J, . Case report: cytokine and CD4+ T-cell profiles of monozygotic twins with autism and divergent comorbidities and drug treatment. J Child Neurol. 2015 Mar;30(3):386–90. doi: 10.1177/0883073814529821. X-124736120
3804 Mahajan R, Mostofsky SH. Neuroimaging endophenotypes in autism spectrum disorder. CNS Spectr. 2015 Aug;20(4):412–26. doi: 10.1017/s1092852915000371. X-126234701
3805 Mahajnah M, Sharkia R, Shalabe H, . Clinical characteristics of autism spectrum disorder in Israel: impact of ethnic and social diversities. Biomed Res Int. 2015;2015:962093. doi: 10.1155/2015/962093. X-125984535
3806 Main PA, Thomas P, Angley MT, . Lack of evidence for genomic instability in autistic children as measured by the cytokinesis-block micronucleus cytome assay. Autism Res. 2015 Feb;8(1):94–104. doi: 10.1002/aur.1428. X-125371234
3807 Mak E, Su L, Williams GB, . Neuroimaging correlates of cognitive impairment and dementia in Parkinson’s disease. Parkinsonism Relat Disord. 2015 Aug;21(8):862–70. doi: 10.1016/j.parkreldis.2015.05.013. X-126004683
3808 Malgaz M, van Kesteren CF, Sommer IE. [Auditory verbal hallucinations in an adult with autism spectrum disorder]. Tijdschr Psychiatr. 2015;57(9):684–7. X-126401611
3809 Malhi P, Singhi P. Adaptive Behavior Functioning in Children with Autism. Indian J Pediatr. 2015 Aug;82(8):677–81. doi: 10.1007/s12098-015-1692-8. X-125673293
3810 Mandic-Maravic V, Pejovic-Milovancevic M, Mitkovic-Voncina M, . Sex differences in autism spectrum disorders: does sex moderate the pathway from clinical symptoms to adaptive behavior? Sci Rep. 2015;5:10418. doi: 10.1038/srep10418. X-125988942
3811 Mandy W, Murin M, Baykaner O, . Easing the transition to secondary education for children with autism spectrum disorder: An evaluation of the Systemic Transition in Education Programme for Autism Spectrum Disorder (STEP-ASD). Autism. 2015 Aug 24 doi: 10.1177/1362361315598892. X-1
3812 Mandy W, Tchanturia K. Do women with eating disorders who have social and flexibility difficulties really have autism? A case series. Mol Autism. 2015;6:6. doi: 10.1186/2040-2392-6-6. X-126056560
3813 Manea S, Dalla Pozza LV, Mazzucato M, . Diagnosis of pervasive developmental disorders: when and how? An area-based study about health care providers. World J Pediatr. 2015 Feb;11(1):48–53. doi: 10.1007/s12519-014-0533-6. X-125447633
3814 Mankad D, Dupuis A, Smile S, . A randomized, placebo controlled trial of omega-3 fatty acids in the treatment of young children with autism. Mol Autism. 2015;6:18. doi: 10.1186/s13229-015-0010-7.25798215
3815 Manning C, Morgan M, Allen C, . Do children with autism show reduced susceptibility to the Ebbinghaus illusion? J Vis. 2015 Sep 1;15(12):646. doi: 10.1167/15.12.646. X-1
3816 Manning C, Neil L, Karaminis T, . The effects of grouping on speed discrimination thresholds in adults, typically developing children, and children with autism. J Vis. 2015 Aug 1;15(11):17. doi: 10.1167/15.11.17. X-1
3817 Manschot GM, Hondius AJ, van Dijk MM, . [Resolution of a treatment impasse by combining two Dutch laws regarding a patient with paranoid thoughts and a testicular cancer]. Tijdschr Psychiatr. 2015;57(9):680–3. X-126401610
3818 Margolis SS, Sell GL, Zbinden MA, . Angelman Syndrome. Neurotherapeutics. 2015 Jul;12(3):641–50. doi: 10.1007/s13311-015-0361-y. X-126040994
3819 Mariappan P, Rai B, El-Mokadem I, . Real-life Experience: Early Recurrence With Hexvix Photodynamic Diagnosis-assisted Transurethral Resection of Bladder Tumour vs Good-quality White Light TURBT in New Non-muscle-invasive Bladder Cancer. Urology. 2015 Aug;86(2):327–31. doi: 10.1016/j.urology.2015.04.015. X-126142924
3820 Mari-Bauset S, Llopis-Gonzalez A, Zazpe I, . Nutritional Impact of a Gluten-Free Casein-Free Diet in Children with Autism Spectrum Disorder. J Autism Dev Disord. 2015 Oct 1 doi: 10.1007/s10803-015-2582-7. X-1
3821 Mari-Bauset S, Llopis-Gonzalez A, Zazpe I, . Fat intake in children with autism spectrum disorder in the Mediterranean region (Valencia, Spain). Nutr Neurosci. 2015 May 28 doi: 10.1179/1476830515y.0000000029. X-1
3822 Mark DH, Civic D. Special report: early intensive behavioral intervention and other behavioral interventions for autism spectrum disorder. Technol Eval Cent Assess Program Exec Summ. 2015 Mar;30(1):1–3. X-2
3823 Marko MK, Crocetti D, Hulst T, . Behavioural and neural basis of anomalous motor learning in children with autism. Brain: A Journal of Neurology. 2015;138(3):784–97 14p. doi: brain/awu394. Language: English. Entry Date: 20150508. Revision Date: 20150710. Publication Type: Journal Article. X-125609685
3824 Marrus N, Glowinski AL, Jacob T, . Rapid video-referenced ratings of reciprocal social behavior in toddlers: a twin study. J Child Psychol Psychiatry. 2015 Feb 11 doi: 10.1111/jcpp.12391. X-1
3825 Marshall D, Goodall C. The Right to Appropriate and Meaningful Education for Children with ASD. J Autism Dev Disord. 2015 Oct;45(10):3159–67. doi: 10.1007/s10803-015-2475-9. X-126036647
3826 Marshall J, Hill RJ, Ware RS, . Multidisciplinary intervention for childhood feeding difficulties. J Pediatr Gastroenterol Nutr. 2015 May;60(5):680–7. doi: 10.1097/mpg.0000000000000669. X-125534777
3827 Marshall J, Ware R, Ziviani J, . Efficacy of interventions to improve feeding difficulties in children with autism spectrum disorders: a systematic review and meta-analysis. Child Care Health Dev. 2015 Mar;41(2):278–302. doi: 10.1111/cch.12157. X-224962184
3828 Martin L, Iceberg E. Quantifying Social Motivation in Mice Using Operant Conditioning. J Vis Exp. 2015(102):e53009. doi: 10.3791/53009. X-126327305
3829 Maruani A, Huguet G, Beggiato A, . 11q24.2–25 micro-rearrangements in autism spectrum disorders: Relation to brain structures. Am J Med Genet A. 2015 Sep 3 doi: 10.1002/ajmg.a.37345. X-1
3830 Marzinzik F, Herrmann A, Gogarten JH, . Dysfunctional action control as a specific feature of Parkinson’s disease. J Neural Transm (Vienna). 2015 Aug;122(8):1125–33. doi: 10.1007/s00702-014-1354-4. X-125547860
3831 Masi A, Lampit A, Glozier N, . Predictors of placebo response in pharmacological and dietary supplement treatment trials in pediatric autism spectrum disorder: a meta-analysis. Transl Psychiatry. 2015;5:e640. doi: 10.1038/tp.2015.143. X-226393486
3832 Masi A, Quintana DS, Glozier N, . Cytokine aberrations in autism spectrum disorder: a systematic review and meta-analysis. Mol Psychiatry. 2015 Apr;20(4):440–6. doi: 10.1038/mp.2014.59. X-124934179
3833 Maski K, Holbrook H, Manoach D, . Sleep Dependent Memory Consolidation in Children with Autism Spectrum Disorder. Sleep. 2015 Jul 13. X-1
3834 Masuya Y, Okamoto Y, Inohara K, . Sex-different abnormalities in the right second to fourth digit ratio in Japanese individuals with autism spectrum disorders. Mol Autism. 2015;6:34. doi: 10.1186/s13229-015-0028-x. X-126060570
3835 Matlis S, Boric K, Chu CJ, . Robust disruptions in electroencephalogram cortical oscillations and large-scale functional networks in autism. BMC Neurol. 2015;15:97. doi: 10.1186/s12883-015-0355-8. X-126111798
3836 Matsuda S, Minagawa Y, Yamamoto J. Gaze Behavior of Children with ASD toward Pictures of Facial Expressions. Autism Res Treat. 2015;2015:617190. doi: 10.1155/2015/617190. X-126090223
3837 Matsumoto MM, Matthews KR. A Need for Renewed and Cohesive US Policy on Cord Blood Banking. Stem Cell Rev. 2015 Aug 4 doi: 10.1007/s12015-015-9613-9. X-1
3838 Matsuo J, Kamio Y, Takahashi H, . Autistic-like traits in adult patients with mood disorders and schizophrenia. PLoS One. 2015;10(4):e0122711. doi: 10.1371/journal.pone.0122711. X-125838109
3839 Matsuo M, Fuji A, Matsuzaka T, . [Effectiveness and safety of long-term levetiracetam treatment in patients with refractory epilepsy]. No To Hattatsu. 2015 Jul;47(4):272–8. X-126353448
3840 Matthews NL, Smith CJ, Pollard E, . Adaptive Functioning in Autism Spectrum Disorder During the Transition to Adulthood. J Autism Dev Disord. 2015 Aug;45(8):2349–60. doi: 10.1007/s10803-015-2400-2. X-125733158
3841 Mattison ML, Dando CJ, Ormerod TC. Sketching to remember: episodic free recall task support for child witnesses and victims with autism spectrum disorder. J Autism Dev Disord. 2015 Jun;45(6):1751–65. doi: 10.1007/s10803-014-2335-z. X-125503484
3842 May T, Cornish K, Rinehart NJ. Parent-Child Agreement Using the Spence Children’s Anxiety Scale and a Thermometer in Children with Autism Spectrum Disorder. Autism Res Treat. 2015;2015:315495. doi: 10.1155/2015/315495. X-125922765
3843 May T, Cornish K, Rinehart NJ. Mechanisms of Anxiety Related Attentional Biases in Children with Autism Spectrum Disorder. J Autism Dev Disord. 2015 Oct;45(10):3339–50. doi: 10.1007/s10803-015-2500-z. X-126070278
3844 Mazefsky CA. Emotion Regulation and Emotional Distress in Autism Spectrum Disorder: Foundations and Considerations for Future Research. J Autism Dev Disord. 2015 Nov;45(11):3405–8. doi: 10.1007/s10803-015-2602-7. X-126391886
3845 Mazurek MO, Petroski GF. Sleep problems in children with autism spectrum disorder: examining the contributions of sensory over-responsivity and anxiety. Sleep Med. 2015 Feb;16(2):270–9. doi: 10.1016/j.sleep.2014.11.006. X-125600781
3846 McArthur S, Pienaar IS, Siddiqi SM, . Sex-specific disruption of murine midbrain astrocytic and dopaminergic developmental trajectories following antenatal GC treatment. Brain Struct Funct. 2015 May 6 doi: 10.1007/s00429-015-1049-0. X-1
3847 McConachie H. Appropriate outcome measurement for children with autism spectrum disorder. Dev Med Child Neurol. 2015 Jul 30 doi: 10.1111/dmcn.12862. X-1, X-2
3848 McConachie H, Fletcher-Watson S. Building capacity for rigorous controlled trials in autism: the importance of measuring treatment adherence. Child Care Health Dev. 2015 Mar;41(2):169–77. doi: 10.1111/cch.12185. X-1, X-225163398
3849 McConachie H, Parr JR, Glod M, . Systematic review of tools to measure outcomes for young children with autism spectrum disorder. Health Technol Assess. 2015 Jun;19(41):1–506. doi: 10.3310/hta19410. X-2
3850 McCrimmon AW, Matchullis RL, Altomare AA. Resilience and emotional intelligence in children with high-functioning autism spectrum disorder. Dev Neurorehabil. 2015 Aug 24:1–8. doi: 10.3109/17518423.2014.927017. X-1
3851 McDermott S, Hardin JW, Royer JA, . Emergency department and inpatient hospitalizations for young people with fragile X syndrome. Am J Intellect Dev Disabil. 2015 May;120(3):230–43. doi: 10.1352/1944-7558-120.3.230. X-125928435
3852 McDonnell A, McCreadie M, Mills R, . The role of physiological arousal in the management of challenging behaviours in individuals with autistic spectrum disorders. Research in Developmental Disabilities. 2015 2015-12-09;36:311–22. doi: http://dx.doi.org/10.1016/j.ridd.2014.09.012; 2014-54687-033. X-1
3853 McDuffie A, Thurman AJ, Hagerman RJ, . Symptoms of Autism in Males with Fragile X Syndrome: A Comparison to Nonsyndromic ASD Using Current ADI-R Scores. J Autism Dev Disord. 2015 Jul;45(7):1925–37. doi: 10.1007/s10803-013-2013-6. X-124414079
3854 McEvilly M, Wicks S, Dalman C. Sick Leave and Work Participation Among Parents of Children with Autism Spectrum Disorder in the Stockholm Youth Cohort: A Register Linkage Study in Stockholm, Sweden. J Autism Dev Disord. 2015 Jul;45(7):2157–67. doi: 10.1007/s10803-015-2381-1. X-125697737
3855 McGrane IR, Loveland JG, Zaluski HJ, . Serum Quetiapine Concentration Changes with Concomitant Oxcarbazepine Therapy in a Boy with Autism Spectrum Disorder. J Child Adolesc Psychopharmacol. 2015 Oct 15 doi: 10.1089/cap.2015.0117. X-1, X-3, X-4
3856 McGrath LM, Braaten EB, Doty ND, . Extending the ‘cross-disorder’ relevance of executive functions to dimensional neuropsychiatric traits in youth. J Child Psychol Psychiatry. 2015 Sep 28 doi: 10.1111/jcpp.12463. X-1
3857 McHale SM, Updegraff KA, Feinberg ME. Siblings of Youth with Autism Spectrum Disorders: Theoretical Perspectives on Sibling Relationships and Individual Adjustment. J Autism Dev Disord. 2015 Oct 17 doi: 10.1007/s10803-015-2611-6. X-1
3858 McKean SJ, Bartell SM, Hansen RL, . Prenatal mercury exposure, autism, and developmental delay, using pharmacokinetic combination of newborn blood concentrations and questionnaire data: a case control study. Environ Health. 2015;14:62. doi: 10.1186/s12940-015-0045-4. X-126198445
3859 McKenna PE, Glass A, Rajendran G, . Strange Words: Autistic Traits and the Processing of Non-Literal Language. J Autism Dev Disord. 2015 Nov;45(11):3606–12. doi: 10.1007/s10803-015-2508-4. X-126093391
3860 McKenney EL, Bristol RM. Supporting intensive interventions for students with autism spectrum disorder: performance feedback and discrete trial teaching. Sch Psychol Q. 2015 Mar;30(1):8–22. doi: 10.1037/spq0000060. X-124884446
3861 McLay LK, France K. Empirical research evaluating non-traditional approaches to managing sleep problems in children with autism. Dev Neurorehabil. 2015 Aug 24:1–12. doi: 10.3109/17518423.2014.904452. X-1, X-2
3862 McLeod BD, Wood JJ, Klebanoff S. Advances in evidence-based intervention and assessment practices for youth with an autism spectrum disorder. Behav Ther. 2015 Jan;46(1):1–6. doi: 10.1016/j.beth.2014.07.004. X-125526830
3863 McMahon CM, Henderson HA. Error-monitoring in response to social stimuli in individuals with higher-functioning Autism Spectrum Disorder. Dev Sci. 2015 May;18(3):389–403. doi: 10.1111/desc.12220. X-125066088
3864 McMahon CM, Solomon M. Brief Report: Parent-Adolescent Informant Discrepancies of Social Skill Importance and Social Skill Engagement for Higher-Functioning Adolescents with Autism Spectrum Disorder. J Autism Dev Disord. 2015 Oct;45(10):3396–403. doi: 10.1007/s10803-015-2494-6. X-126077952
3865 McMahon JJ, Yu W, Yang J, . Seizure-dependent mTOR activation in 5-HT neurons promotes autism-like behaviors in mice. Neurobiol Dis. 2015 Jan;73:296–306. doi: 10.1016/j.nbd.2014.10.004. X-125315683
3866 Meguid NA, Gebril OH, Khalil RO. A study of blood serotonin and serotonin transporter promoter variant (5-HTTLPR) polymorphism in Egyptian autistic children. Adv Biomed Res. 2015;4:94. doi: 10.4103/2277-9175.156658. X-126015920
3867 Mehling MH, Tasse MJ. Impact of Choice on Social Outcomes of Adults with ASD. J Autism Dev Disord. 2015 Jun;45(6):1588–602. doi: 10.1007/s10803-014-2312-6. X-125413143
3868 Mehta B, Chawla VK, Parakh M, . ABER Assessment in Pre-school Children with Developmental Speech and Language Impairment. J Clin Diagn Res. 2015 May;9(5):Cc01–3. doi: 10.7860/jcdr/2015/13723.5873. X-1
3869 Mehta UM, Waghmare AV, Thirthalli J, . Is the human mirror neuron system plastic? Evidence from a transcranial magnetic stimulation study. Asian J Psychiatr. 2015 Jul 8 doi: 10.1016/j.ajp.2015.06.014. X-1
3870 Meilleur A-A, Jelenic P, Mottron L. Prevalence of Clinically and Empirically Defined Talents and Strengths in Autism. Journal of Autism & Developmental Disorders. 2015;45(5):1354–67 14p. doi: 10.1007/s10803-014-2296-2. Language: English. Entry Date: 20150424. Revision Date: 20150710. Publication Type: Journal Article. X-125374134
3871 Merrick H, McConachie H, Le Couteur A, . Characteristics of young people with long term conditions close to transfer to adult health services. BMC Health Serv Res. 2015;15(1):435. doi: 10.1186/s12913-015-1095-6. X-126424085
3872 Messinger DS, Young GS, Webb SJ, . Early sex differences are not autism-specific: A Baby Siblings Research Consortium (BSRC) study. Mol Autism. 2015;6:32. doi: 10.1186/s13229-015-0027-y. X-126045943
3873 Meziane H, Schaller F, Bauer S, . An Early Postnatal Oxytocin Treatment Prevents Social and Learning Deficits in Adult Mice Deficient for Magel2, a Gene Involved in Prader-Willi Syndrome and Autism. Biol Psychiatry. 2015 Jul 15;78(2):85–94. doi: 10.1016/j.biopsych.2014.11.010. X-125599930
3874 Mikita N, Hollocks MJ, Papadopoulos AS, . Irritability in boys with autism spectrum disorders: an investigation of physiological reactivity. J Child Psychol Psychiatry. 2015 Oct;56(10):1118–26. doi: 10.1111/jcpp.12382. X-125626926
3875 Miller SA, Rodriguez NM, Rourke AJ. Do mirrors facilitate acquisition of motor imitation in children diagnosed with autism? J Appl Behav Anal. 2015 Spring;48(1):194–8. doi: 10.1002/jaba.187. X-1, X-3, X-425684255
3876 Mimouni-Bloch A, Yeshaya J, Kahana S, . A de-novo interstitial microduplication involving 2p16.1-p15 and mirroring 2p16.1-p15 microdeletion syndrome: Clinical and molecular analysis. Eur J Paediatr Neurol. 2015 Nov;19(6):711–5. doi: 10.1016/j.ejpn.2015.07.013. X-126278498
3877 Minhas A, Vajaratkar V, Divan G, . Parents’ perspectives on care of children with autistic spectrum disorder in South Asia - Views from Pakistan and India. Int Rev Psychiatry. 2015;27(3):247–56. doi: 10.3109/09540261.2015.1049128. X-126107996
3878 Minnes P, Perry A, Weiss JA. Predictors of distress and well-being in parents of young children with developmental delays and disabilities: the importance of parent perceptions. J Intellect Disabil Res. 2015 Jun;59(6):551–60. doi: 10.1111/jir.12160. X-125169777
3879 Minshawi NF, Hurwitz S, Morriss D, . Multidisciplinary assessment and treatment of self-injurious behavior in autism spectrum disorder and intellectual disability: integration of psychological and biological theory and approach. J Autism Dev Disord. 2015 Jun;45(6):1541–68. doi: 10.1007/s10803-014-2307-3. X-1, X-225395094
3880 Mirabella AC, Foster BM, Bartke T. Chromatin deregulation in disease. Chromosoma. 2015 Jul 19 doi: 10.1007/s00412-015-0530-0. X-1
3881 Mirabella G. Is art therapy a reliable tool for rehabilitating people suffering from brain/mental diseases? J Altern Complement Med. 2015 Apr;21(4):196–9. doi: 10.1089/acm.2014.0374. X-125848886
3882 Miron O, Ari-Even Roth D, Gabis LV, . Prolonged auditory brainstem responses in infants with autism. Autism Res. 2015 Oct 19 doi: 10.1002/aur.1561. X-1
3883 Misic B, Doesburg SM, Fatima Z, . Coordinated Information Generation and Mental Flexibility: Large-Scale Network Disruption in Children with Autism. Cereb Cortex. 2015 Sep;25(9):2815–27. doi: 10.1093/cercor/bhu082. X-1, X-224770713
3884 Mitchell ES, Mrug S, Patterson CS, . Summer Treatment Program Improves Behavior of Children with High-Functioning Autism Spectrum Disorder. J Autism Dev Disord. 2015 Aug;45(8):2295–310. doi: 10.1007/s10803-014-2241-4. X-1, X-325503679
3885 Mitchell GE, Locke KD. Lay beliefs about autism spectrum disorder among the general public and childcare providers. Autism. 2015 Jul;19(5):553–61. doi: 10.1177/1362361314533839. X-124852751
3886 Mitteer DR, Romani PW, Greer BD, . Assessment and treatment of pica and destruction of holiday decorations. J Appl Behav Anal. 2015 Sep 18 doi: 10.1002/jaba.255. X-1, X-3, X-4
3887 Mohammadian M, Zarafshan H, Mohammadi MR, . Evaluating Reliability and Predictive Validity of the Persian Translation of Quantitative Checklist for Autism in Toddlers (Q-CHAT). Iran J Psychiatry. 2015;10(1):64–70. X-126005483
3888 Mohammadzaheri F, Koegel LK, Rezaei M, . A Randomized Clinical Trial Comparison Between Pivotal Response Treatment (PRT) and Adult-Driven Applied Behavior Analysis (ABA) Intervention on Disruptive Behaviors in Public School Children with Autism. J Autism Dev Disord. 2015 Sep;45(9):2899–907. doi: 10.1007/s10803-015-2451-4. X-125953148
3889 Moieni M, Irwin MR, Jevtic I, . Inflammation impairs social cognitive processing: A randomized controlled trial of endotoxin. Brain Behav Immun. 2015 Aug;48:132–8. doi: 10.1016/j.bbi.2015.03.002. X-125770082
3890 Molesworth C, Chevallier C, Happe F, . Children with autism do not show sequence effects with auditory stimuli. J Exp Psychol Gen. 2015 Feb;144(1):48–57. doi: 10.1037/a0038204. X-125365532
3891 Moore DJ, Reidy J, Heavey L. Attentional allocation of autism spectrum disorder individuals: Searching for a Face-in-the-Crowd. Autism. 2015 Mar 13 doi: 10.1177/1362361315573637. X-1
3892 Moore DW, Venkatesh S, Anderson A, . TOBY play-pad application to teach children with ASD - A pilot trial. Dev Neurorehabil. 2015;18(4):213–7. doi: 10.3109/17518423.2013.784817. X-1, X-323869435
3893 Moore KM, Cividini-Motta C, Clark KM, . Sensory integration as a treatment for automatically maintained stereotypy. Behavioral Interventions. 2015 2015-06-04;30(2):95–111. doi: 10.1901/jaba.1994.27-197. (Reprinted from Analysis and Intervention in Developmental Disabilities, 1982, Vol. 2, pp. 3–20) http://dx.doi.org/10.1002/bin.1405; 2015-19248-001. X-1, X-3, X-4
3894 Mori K, Toda Y, Ito H, . Neuroimaging in autism spectrum disorders: 1H-MRS and NIRS study. J Med Invest. 2015;62(1–2):29–36. doi: 10.2152/jmi.62.29. X-125817280
3895 Morin K, Guy J, Habak C, . Atypical Face Perception in Autism: A Point of View? Autism Res. 2015 Oct;8(5):497–506. doi: 10.1002/aur.1464. X-125683613
3896 Morris SL, Foster CJ, Parsons R, . Differences in the use of vision and proprioception for postural control in autism spectrum disorder. Neuroscience. 2015 Oct 29;307:273–80. doi: 10.1016/j.neuroscience.2015.08.040. X-126314635
3897 Moseley RL, Shtyrov Y, Mohr B, . Lost for emotion words: what motor and limbic brain activity reveals about autism and semantic theory. Neuroimage. 2015 Jan 1;104:413–22. doi: 10.1016/j.neuroimage.2014.09.046. X-125278250
3898 Moses L, Katz N, Weizman A. Impact of epilepsy and antiepileptic medications on the metabolic profile in adults with autism spectrum disorder and intellectual disabilities. Int Clin Psychopharmacol. 2015 Nov;30(6):351–5. doi: 10.1097/yic.0000000000000089. X-126186174
3899 Mosienko V, Beis D, Alenina N, . Reduced isolation-induced pup ultrasonic communication in mouse pups lacking brain serotonin. Mol Autism. 2015;6:13. doi: 10.1186/s13229-015-0003-6. X-125901271
3900 Mouga S, Almeida J, Cafe C, . Adaptive profiles in autism and other neurodevelopmental disorders. J Autism Dev Disord. 2015 Apr;45(4):1001–12. doi: 10.1007/s10803-014-2256-x. X-125241010
3901 Muehlmann AM, Bliznyuk N, Duerr I, . Repetitive motor behavior: further characterization of development and temporal dynamics. Dev Psychobiol. 2015 Mar;57(2):201–11. doi: 10.1002/dev.21279. X-125631623
3902 Mukherjee SB, Malhotra MK, Aneja S, . Diagnostic accuracy of Indian Scale for Assessment of Autism (ISAA) in chidren aged 2–9 years. Indian Pediatr. 2015 Mar 8;52(3):212–6. X-125848996
3903 Mullegama SV, Alaimo JT, Chen L, . Phenotypic and molecular convergence of 2q23.1 deletion syndrome with other neurodevelopmental syndromes associated with autism spectrum disorder. Int J Mol Sci. 2015;16(4):7627–43. doi: 10.3390/ijms16047627. X-125853262
3904 Mullegama SV, Pugliesi L, Burns B, . MBD5 haploinsufficiency is associated with sleep disturbance and disrupts circadian pathways common to Smith-Magenis and fragile X syndromes. Eur J Hum Genet. 2015 Jun;23(6):781–9. doi: 10.1038/ejhg.2014.200. X-125271084
3905 Munde V, Vlaskamp C, Ter Haar A. Social-emotional instability in individuals with Rett syndrome: parents’ experiences with second stage behaviour. J Intellect Disabil Res. 2015 Oct 14 doi: 10.1111/jir.12233. X-1
3906 Muneoka K, Kuwagata M, Ogawa T, . Mother/offspring co-administration of the traditional herbal remedy yokukansan during the nursing period influences grooming and cerebellar serotonin levels in a rat model of neurodevelopmental disorders. Cerebellum. 2015 Apr;14(2):86–96. doi: 10.1007/s12311-014-0611-2. X-125315739
3907 Munoz Lasa S, Maximo Bocanegra N, Valero Alcaide R, . Animal assisted interventions in neurorehabilitation: a review of the most recent literature. Neurologia. 2015 Jan–Feb;30(1):1–7. doi: 10.1016/j.nrl.2013.01.012. X-1, X-223642347
3908 Murdaugh DL, Deshpande HD, Kana RK. The Impact of Reading Intervention on Brain Responses Underlying Language in Children With Autism. Autism Res. 2015 May 25 doi: 10.1002/aur.1503. X-1
3909 Murdaugh DL, Maximo JO, Kana RK. Changes in intrinsic connectivity of the brain’s reading network following intervention in children with autism. Hum Brain Mapp. 2015 Aug;36(8):2965–79. doi: 10.1002/hbm.22821. X-126058572
3910 Murray K, Jassi A, Mataix-Cols D, . Outcomes of cognitive behaviour therapy for obsessive-compulsive disorder in young people with and without autism spectrum disorders: A case controlled study. Psychiatry Res. 2015 Jul 30;228(1):8–13. doi: 10.1016/j.psychres.2015.03.012. X-1, X-325935374
3911 Muskat B, Burnham Riosa P, Nicholas DB, . Autism comes to the hospital: The experiences of patients with autism spectrum disorder, their parents and health-care providers at two Canadian paediatric hospitals. Autism: The International Journal of Research & Practice. 2015;19(4):482–90 9p. doi: 10.1177/1362361314531341. Language: English. Entry Date: 20150416. Revision Date: 20150710. Publication Type: Journal Article. X-124811967
3912 Mussey JL, Travers BG, Klinger LG, . Decision-making skills in ASD: performance on the Iowa Gambling Task. Autism Res. 2015 Feb;8(1):105–14. doi: 10.1002/aur.1429. X-125371315
3913 Must A, Phillips S, Curtin C, . Barriers to Physical Activity in Children With Autism Spectrum Disorders: Relationship to Physical Activity and Screen Time. J Phys Act Health. 2015 Apr;12(4):529–34. doi: 10.1123/jpah.2013-0271. X-125920014
3914 Mutluer T, Karakoc Demirkaya S, Abali O. Assessment of sleep problems and related risk factors observed in Turkish children with Autism spectrum disorders. Autism Res. 2015 Oct 13 doi: 10.1002/aur.1542. X-1
3915 Myers E, Davis BE, Stobbe G, . Community and Social Participation Among Individuals with Autism Spectrum Disorder Transitioning to Adulthood. J Autism Dev Disord. 2015 Aug;45(8):2373–81. doi: 10.1007/s10803-015-2403-z. X-125725812
3916 Nadeau JM, Arnold EB, Keene AC, . Frequency and Clinical Correlates of Sleep-Related Problems Among Anxious Youth with Autism Spectrum Disorders. Child Psychiatry Hum Dev. 2015 Aug;46(4):558–66. doi: 10.1007/s10578-014-0496-9. X-1, X-325239284
3917 Najjar F, Owley T, Mosconi MW, . Pharmacogenetic Study of Serotonin Transporter and 5HT2A Genotypes in Autism. J Child Adolesc Psychopharmacol. 2015 Aug;25(6):467–74. doi: 10.1089/cap.2014.0158. X-326262902
3918 Nakamura T, Matsumoto J, Takamura Y, . Relationships among parvalbumin-immunoreactive neuron density, phase-locked gamma oscillations, and autistic/schizophrenic symptoms in PDGFR-beta knock-out and control mice. PLoS One. 2015;10(3):e0119258. doi: 10.1371/journal.pone.0119258. X-125803852
3919 Nakamura T, Oinuma T, Yamagishi H, . Evaluation of a novel high-resolution magnifying videoendoscope that is capable of photodynamic diagnosis and therapy for gastric cancer. Photodiagnosis Photodyn Ther. 2015 Mar;12(1):115–22. doi: 10.1016/j.pdpdt.2014.10.010. X-125462577
3920 Nance E, Porambo M, Zhang F, . Systemic dendrimer-drug treatment of ischemia-induced neonatal white matter injury. J Control Release. 2015 Sep 28;214:112–20. doi: 10.1016/j.jconrel.2015.07.009. X-126184052
3921 Narzisi A, Muratori F, Buscema M, . Outcome predictors in autism spectrum disorders preschoolers undergoing treatment as usual: insights from an observational study using artificial neural networks. Neuropsychiatr Dis Treat. 2015;11:1587–99. doi: 10.2147/ndt.s81233. X-126170671
3922 Navarro D, Alvarado M, Navarrete F, . Gestational and early postnatal hypothyroidism alters VGluT1 and VGAT bouton distribution in the neocortex and hippocampus, and behavior in rats. Front Neuroanat. 2015;9:9. doi: 10.3389/fnana.2015.00009. X-125741243
3923 Navarro E, Araya M. [Non-celiac gluten sensitivity: Another condition that responds to gluten]. Rev Med Chil. 2015 May;143(5):619–26. doi: 10.4067/s0034-98872015000500010. X-1, X-226203574
3924 Navarro F, Pearson DA, Fatheree N, . Are ‘leaky gut’ and behavior associated with gluten and dairy containing diet in children with autism spectrum disorders? Nutr Neurosci. 2015 May;18(4):177–85. doi: 10.1179/1476830514y.0000000110.24564346
3925 Naviaux JC, Wang L, Li K, . Antipurinergic therapy corrects the autism-like features in the Fragile X (Fmr1 knockout) mouse model. Mol Autism. 2015;6:1. doi: 10.1186/2040-2392-6-1. X-125705365
3926 Nazneen N, Rozga A, Smith CJ, . A Novel System for Supporting Autism Diagnosis Using Home Videos: Iterative Development and Evaluation of System Design. JMIR Mhealth Uhealth. 2015;3(2):e68. doi: 10.2196/mhealth.4393. X-126085230
3927 Neely L, Rispoli M, Gerow S, . Effects of antecedent exercise on academic engagement and stereotypy during instruction. Behav Modif. 2015 Jan;39(1):98–116. doi: 10.1177/0145445514552891. X-1, X-3, X-425271070
3928 Nelson CA, Varcin KJ, Coman NK, . Shortened Telomeres in Families With a Propensity to Autism. J Am Acad Child Adolesc Psychiatry. 2015 Jul;54(7):588–94. doi: 10.1016/j.jaac.2015.04.006. X-126088664
3929 Nelson TM, Sheller B, Friedman CS, . Educational and therapeutic behavioral approaches to providing dental care for patients with Autism Spectrum Disorder. Spec Care Dentist. 2015 May–Jun;35(3):105–13. doi: 10.1111/scd.12101. X-1, X-225470557
3930 Neufeld J, Ioannou C, Korb S, . Spontaneous Facial Mimicry is Modulated by Joint Attention and Autistic Traits. Autism Res. 2015 Oct 7 doi: 10.1002/aur.1573. X-1
3931 Neuhaus E, Bernier RA, Beauchaine TP. Children with Autism Show Altered Autonomic Adaptation to Novel and Familiar Social Partners. Autism Res. 2015 Aug 25 doi: 10.1002/aur.1543. X-1
3932 Neuhaus E, Bernier RA, Beauchaine TP. Electrodermal Response to Reward and Non-Reward Among Children With Autism. Autism Res. 2015 Aug;8(4):357–70. doi: 10.1002/aur.1451. X-125599655
3933 Ng R, Brown TT, Erhart M, . Morphological differences in the mirror neuron system in Williams syndrome. Soc Neurosci. 2015 Aug 18:1–12. doi: 10.1080/17470919.2015.1070746. X-1
3934 Ngounou Wetie AG, Wormwood KL, Charette L, . Comparative two-dimensional polyacrylamide gel electrophoresis of the salivary proteome of children with autism spectrum disorder. J Cell Mol Med. 2015 Aug 20 doi: 10.1111/jcmm.12658. X-1
3935 Ngounou Wetie AG, Wormwood KL, Russell S, . A Pilot Proteomic Analysis of Salivary Biomarkers in Autism Spectrum Disorder. Autism Res. 2015 Jun;8(3):338–50. doi: 10.1002/aur.1450. X-125626423
3936 Nguyen CT, Fairclough DL, Noll RB. Problem-solving skills training for mothers of children recently diagnosed with autism spectrum disorder: A pilot feasibility study. Autism. 2015 Apr 20 doi: 10.1177/1362361314567134. X-1
3937 Nickel RE, Huang-Storms L. Early Identification of Young Children with Autism Spectrum Disorder. Indian J Pediatr. 2015 Sep 28 doi: 10.1007/s12098-015-1894-0. X-1
3938 Nielsen S, Anckarsater H, Gillberg C, . Effects of autism spectrum disorders on outcome in teenage-onset anorexia nervosa evaluated by the Morgan-Russell outcome assessment schedule: a controlled community-based study. Mol Autism. 2015;6:14. doi: 10.1186/s13229-015-0013-4. X-125774282
3939 Nikiforuk A. Targeting the Serotonin 5-HT7 Receptor in the Search for Treatments for CNS Disorders: Rationale and Progress to Date. CNS Drugs. 2015 Apr;29(4):265–75. doi: 10.1007/s40263-015-0236-0. X-125721336
3940 Nikoo M, Radnia H, Farokhnia M, . N-acetylcysteine as an adjunctive therapy to risperidone for treatment of irritability in autism: a randomized, double-blind, placebo-controlled clinical trial of efficacy and safety. Clin Neuropharmacol. 2015 Jan–Feb;38(1):11–7. doi: 10.1097/wnf.0000000000000063.25580916
3941 Nishijo M, Tai PT, Anh NT, . Urinary amino acid alterations in 3-year-old children with neurodevelopmental effects due to perinatal dioxin exposure in Vietnam: a nested case-control study for neurobiomarker discovery. PLoS One. 2015;10(1):e0116778. doi: 10.1371/journal.pone.0116778. X-125584822
3942 Nomi JS, Uddin LQ. Developmental changes in large-scale network connectivity in autism. Neuroimage Clin. 2015;7:732–41. doi: 10.1016/j.nicl.2015.02.024. X-125844325
3943 Noor A, Dupuis L, Mittal K, . 15q11.2 Duplication Encompassing Only the UBE3A Gene Is Associated with Developmental Delay and Neuropsychiatric Phenotypes. Hum Mutat. 2015 Jul;36(7):689–93. doi: 10.1002/humu.22800. X-125884337
3944 Nordahl CW, Iosif AM, Young GS, . Sex differences in the corpus callosum in preschool-aged children with autism spectrum disorder. Mol Autism. 2015;6:26. doi: 10.1186/s13229-015-0005-4. X-125973163
3945 Noriega G. A neural model to study sensory abnormalities and multisensory effects in autism. IEEE Trans Neural Syst Rehabil Eng. 2015 Mar;23(2):199–209. doi: 10.1109/tnsre.2014.2363775. X-125343764
3946 Norrelgen F, Fernell E, Eriksson M, . Children with autism spectrum disorders who do not develop phrase speech in the preschool years. Autism. 2015 Nov;19(8):934–43. doi: 10.1177/1362361314556782. X-125488002
3947 Northrup JB, Iverson JM. Vocal Coordination During Early Parent-Infant Interactions Predicts Language Outcome in Infant Siblings of Children with Autism Spectrum Disorder. Infancy. 2015 Sep–Oct;20(5):523–47. X-126345517
3948 Nottingham CL, Vladescu JC, Kodak TM. Incorporating additional targets into learning trials for individuals with autism spectrum disorder. J Appl Behav Anal. 2015 Spring;48(1):227–32. doi: 10.1002/jaba.179. X-1, X-225376814
3949 Nowack N, Wittsiepe J, Kasper-Sonnenberg M, . Influence of Low-Level Prenatal Exposure to PCDD/Fs and PCBs on Empathizing, Systemizing and Autistic Traits: Results from the Duisburg Birth Cohort Study. PLoS One. 2015;10(6):e0129906. doi: 10.1371/journal.pone.0129906. X-126066795
3950 Nowell KP, Schanding GT, Jr., Kanne SM, . Cognitive Profiles in Youth with Autism Spectrum Disorder: An Investigation of Base Rate Discrepancies using the Differential Ability Scales--Second Edition. J Autism Dev Disord. 2015 Jul;45(7):1978–88. doi: 10.1007/s10803-014-2356-7. X-125614020
3951 Nunes ML, Bruni O. Insomnia in childhood and adolescence: clinical aspects, diagnosis, and therapeutic approach. J Pediatr (Rio J). 2015 Sep 18 doi: 10.1016/j.jped.2015.08.006. X-1
3952 Nuske HJ, Vivanti G, Dissanayake C. No Evidence of Emotional Dysregulation or Aversion to Mutual Gaze in Preschoolers with Autism Spectrum Disorder: An Eye-Tracking Pupillometry Study. J Autism Dev Disord. 2015 Nov;45(11):3433–45. doi: 10.1007/s10803-015-2479-5. X-126031923
3953 Nuzzi LC, Pike CM, Lewine EB, . Preoperative electrocardiograms for nonsyndromic children with hand syndactyly. J Hand Surg Am. 2015 Mar;40(3):452–5. doi: 10.1016/j.jhsa.2014.10.053. X-125542431
3954 Nystrom P, Gredeback G, Bolte S, . Hypersensitive pupillary light reflex in infants at risk for autism. Mol Autism. 2015;6:10. doi: 10.1186/s13229-015-0011-6. X-125750705
3955 Oakley C, Mahone EM, Morris-Berry C, . Primary complex motor stereotypies in older children and adolescents: clinical features and longitudinal follow-up. Pediatr Neurol. 2015 Apr;52(4):398–403.e1. doi: 10.1016/j.pediatrneurol.2014.11.002. X-125661287
3956 Obeid R, Daou N, DeNigris D, . A Cross-Cultural Comparison of Knowledge and Stigma Associated with Autism Spectrum Disorder Among College Students in Lebanon and the United States. J Autism Dev Disord. 2015 Nov;45(11):3520–36. doi: 10.1007/s10803-015-2499-1. X-126084712
3957 Oberg E, Givant C, Fisk B, . Epigenetics in Clinical Practice: Characterizing Patient and Provider Experiences with MTHFR Polymorphisms and Methylfolate. J Nutrigenet Nutrigenomics. 2015;8(3):137–50. doi: 10.1159/000440700. X-126484755
3958 Ochiai M, Ichiyama M, Iwayama M, . Longitudinal study of very low birth weight infants until 9years of age; attention deficit hyperactivity and autistic features are correlated with their cognitive functions. Early Hum Dev. 2015 Oct 3 doi: 10.1016/j.earlhumdev.2015.09.005. X-1
3959 Ockeloen CW, Willemsen MH, de Munnik S, . Further delineation of the KBG syndrome phenotype caused by ANKRD11 aberrations. Eur J Hum Genet. 2015 Sep;23(9):1176–85. doi: 10.1038/ejhg.2014.253. X-125424714
3960 Oddi D, Subashi E, Middei S, . Early social enrichment rescues adult behavioral and brain abnormalities in a mouse model of fragile X syndrome. Neuropsychopharmacology. 2015 Apr;40(5):1113–22. doi: 10.1038/npp.2014.291. X-125348604
3961 Odell AP. Treatment Challenges in Special Populations: High-functioning Autistic Patients with Pain. Journal for Nurse Practitioners. 2015;11(4):466–7 2p. doi: 10.1016/j.nurpra.2014.11.020. Language: English. Entry Date: 20150618. Revision Date: 20151008. Publication Type: Journal Article. X-1
3962 Odriozola P, Uddin LQ, Lynch CJ, . Insula response and connectivity during social and non-social attention in children with autism. Soc Cogn Affect Neurosci. 2015 Oct 9 doi: 10.1093/scan/nsv126. X-1
3963 Oguro-Ando A, Rosensweig C, Herman E, . Increased CYFIP1 dosage alters cellular and dendritic morphology and dysregulates mTOR. Mol Psychiatry. 2015 Sep;20(9):1069–78. doi: 10.1038/mp.2014.124. X-125311365
3964 Oh S, Ji H, Barzman D, . Pediatric asthma and autism-genomic perspectives. Clin Transl Med. 2015 Dec;4(1):37. doi: 10.1186/s40169-015-0078-x. X-126668064
3965 Oh YS, Kim JS, Lee PH. Effect of Rivastigmine on Behavioral and Psychiatric Symptoms of Parkinson’s Disease Dementia. J Mov Disord. 2015 May;8(2):98–102. doi: 10.14802/jmd.15041. X-126090082
3966 O’Haire ME, McKenzie SJ, Beck AM, . Animals may act as social buffers: Skin conductance arousal in children with autism spectrum disorder in a social context. Dev Psychobiol. 2015 Jul;57(5):584–95. doi: 10.1002/dev.21310. X-1, X-325913902
3967 Ohan JL, Ellefson SE, Corrigan PW. Brief Report: The Impact of Changing from DSM-IV ‘Asperger’s’ to DSM-5 ‘Autistic Spectrum Disorder’ Diagnostic Labels on Stigma and Treatment Attitudes. J Autism Dev Disord. 2015 Oct;45(10):3384–9. doi: 10.1007/s10803-015-2485-7. X-126043847
3968 O’Hearn K, Velanova K, Lynn A, . Abnormalities in brain systems supporting individuation and enumeration in autism. Autism Res. 2015 May 26 doi: 10.1002/aur.1498. X-1
3969 Ohta H, Nordahl CW, Iosif AM, . Increased Surface Area, but not Cortical Thickness, in a Subset of Young Boys With Autism Spectrum Disorder. Autism Res. 2015 Jul 16 doi: 10.1002/aur.1520. X-1
3970 Oien R, Eisemann MR. Brief Report: Parent-Reported Problems Related to Communication, Behavior and Interests in Children with Autistic Disorder and Their Impact on Quality of Life. J Autism Dev Disord. 2015 Oct 5 doi: 10.1007/s10803-015-2577-4. X-1
3971 Okazaki R, Takahashi T, Ueno K, . Changes in EEG complexity with electroconvulsive therapy in a patient with autism spectrum disorders: a multiscale entropy approach. Front Hum Neurosci. 2015;9:106. doi: 10.3389/fnhum.2015.00106. X-125767444
3972 Olde Loohuis NF, Kole K, Glennon JC, . Elevated microRNA-181c and microRNA-30d levels in the enlarged amygdala of the valproic acid rat model of autism. Neurobiol Dis. 2015 Aug;80:42–53. doi: 10.1016/j.nbd.2015.05.006. X-125986729
3973 Olfson M, King M, Schoenbaum M. Treatment of Young People With Antipsychotic Medications in the United States. JAMA Psychiatry. 2015 Sep;72(9):867–74. doi: 10.1001/jamapsychiatry.2015.0500. X-126132724
3974 Ollington N. Comparison of a direct and an indirect approach for the functional assessment of insistence on sameness in a child with autism spectrum disorder and a typically developing child. Dev Neurorehabil. 2015 Aug 24:1–8. doi: 10.3109/17518423.2014.898161. X-1
3975 Olsson MB, Westerlund J, Lundstrom S, . “Recovery” from the diagnosis of autism - and then? Neuropsychiatr Dis Treat. 2015;11:999–1005. doi: 10.2147/ndt.s78707. X-1, X-325897237
3976 Olzenak DL. The Association between Motor Proficiency and Participation in School-aged Children with Autism Spectrum Disorder: University of Rochester; 2015.
3977 Omura Y, Lu D, Jones MK, . Early Detection of Autism (ASD) by a Non-invasive Quick Measurement of Markedly Reduced Acetylcholine & DHEA and Increased beta-Amyloid (1–42), Asbestos (Chrysotile), Titanium Dioxide, Al, Hg & often Coexisting Virus Infections (CMV, HPV 16 and 18), Bacterial Infections etc. in the Brain and Corresponding Safe Individualized Effective Treatment. Acupunct Electrother Res. 2015;40(3):157–87. X-126829843
3978 Ong WY, Farooqui T, Kokotos G, . Synthetic and natural inhibitors of phospholipases A2: their importance for understanding and treatment of neurological disorders. ACS Chem Neurosci. 2015 Jun 17;6(6):814–31. doi: 10.1021/acschemneuro.5b00073. X-125891385
3979 Ooi YP, Weng SJ, Jang LY, . Omega-3 fatty acids in the management of autism spectrum disorders: findings from an open-label pilot study in Singapore. Eur J Clin Nutr. 2015 Aug;69(8):969–71. doi: 10.1038/ejcn.2015.28. X-325804268
3980 Orinstein A, Tyson KE, Suh J, . Psychiatric Symptoms in Youth with a History of Autism and Optimal Outcome. J Autism Dev Disord. 2015 Nov;45(11):3703–14. doi: 10.1007/s10803-015-2520-8. X-126155764
3981 Orinstein AJ, Suh J, Porter K, . Social Function and Communication in Optimal Outcome Children and Adolescents with an Autism History on Structured Test Measures. J Autism Dev Disord. 2015 Aug;45(8):2443–63. doi: 10.1007/s10803-015-2409-6. X-125758821
3982 Orsmond GI, Cohn ES. The Distinctive Features of a Feasibility Study: Objectives and Guiding Questions. OTJR (Thorofare N J). 2015 Jul;35(3):169–77. X-126594739
3983 Osiecka BJ, Jurczyszyn K, Nockowski P, . Using photodynamic therapy to estimate effectiveness of innovative combined diclofenac and tazaroten therapy of disseminated actinic keratosis. Acta Dermatovenerol Croat. 2015;23(1):52–8. X-125969914
3984 Osipowicz K, Bosenbark DD, Patrick KE. Cortical Changes Across the Autism Lifespan. Autism Res. 2015 Aug;8(4):379–85. doi: 10.1002/aur.1453. X-125630444
3985 Ostfeld-Etzion S, Golan O, Hirschler-Guttenberg Y, . Neuroendocrine and behavioral response to social rupture and repair in preschoolers with autism spectrum disorders interacting with mother and father. Mol Autism. 2015;6:11. doi: 10.1186/s13229-015-0007-2. X-125774280
3986 Oswald TM, Beck JS, Iosif AM, . Clinical and Cognitive Characteristics Associated with Mathematics Problem Solving in Adolescents with Autism Spectrum Disorder. Autism Res. 2015 Sep 29 doi: 10.1002/aur.1524. X-1
3987 Ouchi K, Sugiyama K. Required propofol dose for anesthesia and time to emerge are affected by the use of antiepileptics: prospective cohort study. BMC Anesthesiol. 2015;15:34. doi: 10.1186/s12871-015-0006-z. X-125788855
3988 Ouhtit A, Al-Farsi Y, Al-Sharbati M, . Underlying Factors Behind the Low Prevalence of Autism Spectrum Disorders in Oman: Sociocultural perspective. Sultan Qaboos Univ Med J. 2015 May;15(2):e213–7. X-126052454
3989 Ouwenga RL, Dougherty J. Fmrp targets or not: long, highly brain-expressed genes tend to be implicated in autism and brain disorders. Mol Autism. 2015;6:16. doi: 10.1186/s13229-015-0008-1. X-125789151
3990 Overby CL, Devine EB, Abernethy N, . Making pharmacogenomic-based prescribing alerts more effective: A scenario-based pilot study with physicians. J Biomed Inform. 2015 Jun;55:249–59. doi: 10.1016/j.jbi.2015.04.011. X-125957826
3991 Owen-Smith AA, Bent S, Lynch FL, . Prevalence and Predictors of Complementary and Alternative Medicine Use in a Large Insured Sample of Children with Autism Spectrum Disorders. Res Autism Spectr Disord. 2015 Sep 1;17:40–51. doi: 10.1016/j.rasd.2015.05.002. X-126366192
3992 Pace M, Bricout VA. Low heart rate response of children with autism spectrum disorders in comparison to controls during physical exercise. Physiol Behav. 2015 Mar 15;141:63–8. doi: 10.1016/j.physbeh.2015.01.011. X-125582513
3993 Pack A, Colozzo P, Bernhardt BM, . A case study on vocal loudness with a young adult with autism spectrum disorder and developmental delay. Am J Speech Lang Pathol. 2015 Aug 7 doi: 10.1044/2015_ajslp-14-0209. X-1
3994 Paden AR, Kodak T. The effects of reinforcement magnitude on skill acquisition for children with autism. J Appl Behav Anal. 2015 Aug 17 doi: 10.1002/jaba.239. X-1
3995 Padmanabhan A, Garver K, O’Hearn K, . Developmental changes in brain function underlying inhibitory control in autism spectrum disorders. Autism Res. 2015 Apr;8(2):123–35. doi: 10.1002/aur.1398. X-125382787
3996 Palmer CJ, Paton B, Kirkovski M, . Context sensitivity in action decreases along the autism spectrum: a predictive processing perspective. Proc Biol Sci. 2015 Mar 7;282(1802)doi: 10.1098/rspb.2014.1557. X-1
3997 Palmer EE, Leffler M, Rogers C, . New insights into Brunner syndrome and potential for targeted therapy. Clin Genet. 2015 Mar 23 doi: 10.1111/cge.12589. X-1
3998 Pan CY, Tsai CL, Chu CH, . Objectively Measured Physical Activity and Health-Related Physical Fitness in Secondary School-Aged Male Students With Autism Spectrum Disorders. Phys Ther. 2015 Sep 24 doi: 10.2522/ptj.20140353. X-1
3999 Pan X, Chang X, Leung C, . PAK1 regulates cortical development via promoting neuronal migration and progenitor cell proliferation. Mol Brain. 2015;8:36. doi: 10.1186/s13041-015-0124-z. X-126043730
4000 Pane HM, Sidener TM, Vladescu JC, . Evaluating Function-Based Social Stories With Children With Autism. Behav Modif. 2015 Sep 3 doi: 10.1177/0145445515603708. X-1, X-4
4001 Panigrahi B, Martin KA, Li Y, . Dopamine Is Required for the Neural Representation and Control of Movement Vigor. Cell. 2015 Sep 10;162(6):1418–30. doi: 10.1016/j.cell.2015.08.014. X-126359992
4002 Pantaleon FG, Juvier RT. [Molecular basis of Rett syndrome: A current look]. Rev Chil Pediatr.. 2015 May–Jun;86(3):142–51. doi: 10.1016/j.rchipe.2015.07.001. X-126239053
4003 Paolicchi JM, Ross G, Lee D, . Clobazam and Aggression-Related Adverse Events in Pediatric Patients With Lennox-Gastaut Syndrome. Pediatr Neurol. 2015 Oct;53(4):338–42. doi: 10.1016/j.pediatrneurol.2015.06.021. X-126245776
4004 Papadopoulos N, Sciberras E, Hiscock H, . The Efficacy of a Brief Behavioral Sleep Intervention in School-Aged Children With ADHD and Comorbid Autism Spectrum Disorder. J Atten Disord. 2015 Feb 2 doi: 10.1177/1087054714568565. X-1
4005 Paquet A, Olliac B, Golse B, . Current knowledge on motor disorders in children with autism spectrum disorder (ASD). Child Neuropsychol. 2015 Sep 29:1–32. doi: 10.1080/09297049.2015.1085501. X-1
4006 Parish C. Are we treating or drugging? Learning Disability Practice. 2015;18(5):5- 1p. Language: English. Entry Date: 20150604. Revision Date: 20150710. Publication Type: Journal Article. X-1, X-2
4007 Parisi L, Di Filippo T, Roccella M. Autism spectrum disorder in Kabuki syndrome: clinical, diagnostic and rehabilitative aspects assessed through the presentation of three cases. Minerva Pediatr. 2015 Aug;67(4):369–75. X-126129805
4008 Park EY, Kim J. Factor structure of the childhood autism rating scale as per DSM-5. Pediatr Int.. 2015 Aug 8 doi: 10.1111/ped.12770. X-1
4009 Park HE, Park IS, Oh YS, . Subcortical whiter matter hyperintensities within the cholinergic pathways of patients with dementia and parkinsonism. J Neurol Sci. 2015 Jun 15;353(1–2):44–8. doi: 10.1016/j.jns.2015.03.046. X-125891829
4010 Parr JR, De Jonge MV, Wallace S, . New Interview and Observation Measures of the Broader Autism Phenotype: Description of Strategy and Reliability Findings for the Interview Measures. Autism Res. 2015 Oct;8(5):522–33. doi: 10.1002/aur.1466. X-125959701
4011 Parra MA, Cubelli R, Bellamy KJ, . Gist-based illusions within and across stimulus modalities in autism spectrum disorder. Memory. 2015 Feb 4:1–11. doi: 10.1080/09658211.2015.1004349. X-1
4012 Parsi K, Elster N. A Life of One’s Own: Challenges in the Transition from Childhood to Adulthood with Autism Spectrum Disorder. AMA J Ethics. 2015 Apr;17(4):342–7. doi: 10.1001/journalofethics.2015.17.4.pfor1-1504. X-125901702
4013 Partty A, Kalliomaki M, Wacklin P, . A possible link between early probiotic intervention and the risk of neuropsychiatric disorders later in childhood: a randomized trial. Pediatr Res. 2015 Jun;77(6):823–8. doi: 10.1038/pr.2015.51. X-125760553
4014 Pastor PN, Reuben CA, Kobau R, . Functional difficulties and school limitations of children with epilepsy: findings from the 2009–2010 National Survey of Children with Special Health Care Needs. Disabil Health J. 2015 Apr;8(2):231–9. doi: 10.1016/j.dhjo.2014.09.002. X-125312691
4015 Patel N, Crider A, Pandya CD, . Altered mRNA Levels of Glucocorticoid Receptor, Mineralocorticoid Receptor, and Co-Chaperones (FKBP5 and PTGES3) in the Middle Frontal Gyrus of Autism Spectrum Disorder Subjects. Mol Neurobiol. 2015 Apr 26 doi: 10.1007/s12035-015-9178-2. X-1
4016 Paul AR, McKechanie AG, Johnstone EC, . Brief Report: The Association of Autistic Traits and Behavioural Patterns in Adolescents Receiving Special Educational Assistance. J Autism Dev Disord. 2015 Sep;45(9):3055–60. doi: 10.1007/s10803-015-2445-2. X-125894524
4017 Paynter JM, Keen D. Knowledge and use of intervention practices by community-based early intervention service providers. J Autism Dev Disord. 2015 Jun;45(6):1614–23. doi: 10.1007/s10803-014-2316-2. X-125398604
4018 Pearson A, Marsh L, Ropar D, . Cognitive Mechanisms underlying visual perspective taking in typical and ASC children. Autism Res. 2015 Jun 6 doi: 10.1002/aur.1501. X-1
4019 Pearson BL, Defensor EB, Blanchard DC, . Applying the ethoexperimental approach to neurodevelopmental syndrome research reveals exaggerated defensive behavior in Mecp2 mutant mice. Physiol Behav. 2015 Jul 1;146:98–104. doi: 10.1016/j.physbeh.2015.03.035. X-126066729
4020 Pecorelli A, Cervellati F, Belmonte G, . Cytokines profile and peripheral blood mononuclear cells morphology in Rett and autistic patients. Cytokine. 2015 Oct 12 doi: 10.1016/j.cyto.2015.10.002. X-1
4021 Peiker I, Schneider TR, Milne E, . Stronger Neural Modulation by Visual Motion Intensity in Autism Spectrum Disorders. PLoS One. 2015;10(7):e0132531. doi: 10.1371/journal.pone.0132531. X-126147342
4022 Pellecchia M, Connell JE, Beidas RS, . Dismantling the Active Ingredients of an Intervention for Children with Autism. J Autism Dev Disord. 2015 Sep;45(9):2917–27. doi: 10.1007/s10803-015-2455-0. X-1, X-325911305
4023 Pellecchia M, Connell JE, Kerns CM, . Child characteristics associated with outcome for children with autism in a school-based behavioral intervention. Autism. 2015 Apr 24 doi: 10.1177/1362361315577518. X-1, X-3
4024 Pelly L, Vardy C, Fernandez B, . Incidence and cohort prevalence for autism spectrum disorders in the Avalon Peninsula, Newfoundland and Labrador. CMAJ Open. 2015 Jul–Sep;3(3):E276–80. doi: 10.9778/cmajo.20140056. X-1
4025 Pelz-Sherman D, Olmsted S. Sandplay therapy with individuals on the autism spectrum. Journal of Sandplay Therapy. 2015 2015-07-08;24(1):69–88; 2015-24420-005. X-2, X-3, X-4
4026 Penagarikano O, Lazaro MT, Lu XH, . Exogenous and evoked oxytocin restores social behavior in the Cntnap2 mouse model of autism. Sci Transl Med. 2015 Jan 21;7(271):271ra8. doi: 10.1126/scitranslmed.3010257. X-1
4027 Pence ST, St Peter CC. Evaluation of treatment integrity errors on mand acquisition. J Appl Behav Anal. 2015 Sep;48(3):575–89. doi: 10.1002/jaba.238. X-1, X-3, X-426235379
4028 Penn AH, Carver LJ, Herbert CA, . Breast Milk Protects Against Gastrointestinal Symptoms in Infants at High Risk for Autism During Early Development. J Pediatr Gastroenterol Nutr. 2015 Jul 29 doi: 10.1097/mpg.0000000000000907. X-1
4029 Penner M, Rayar M, Bashir N, . Cost-Effectiveness Analysis Comparing Pre-diagnosis Autism Spectrum Disorder (ASD)-Targeted Intervention with Ontario’s Autism Intervention Program. J Autism Dev Disord. 2015 Sep;45(9):2833–47. doi: 10.1007/s10803-015-2447-0. X-1, X-225936527
4030 Peraza LR, Colloby SJ, Firbank MJ, . Resting state in Parkinson’s disease dementia and dementia with Lewy bodies: commonalities and differences. Int J Geriatr Psychiatry. 2015 Nov;30(11):1135–46. doi: 10.1002/gps.4342. X-126270627
4031 Percinel I, Yazici KU. The Use of Aripiprazole in Young Children with Autism Spectrum Disorders: The Treatment and 16 Week Follow-Up of a 23-Month-old Male Patient. J Child Adolesc Psychopharmacol. 2015 Sep 23 doi: 10.1089/cap.2015.0106. X-3, X-4
4032 Perez-Gonzalez LA, Diaz E, Fernandez-Garcia S, . Stimuli with identical contextual functions taught independently become functionally equivalent. Learn Behav. 2015 Jun;43(2):113–28. doi: 10.3758/s13420-014-0166-6. X-125673100
4033 Perkins TJ, Bittar RG, McGillivray JA, . Increased premotor cortex activation in high functioning autism during action observation. J Clin Neurosci. 2015 Apr;22(4):664–9. doi: 10.1016/j.jocn.2014.10.007. X-125726458
4034 Perreault A, Habak C, Lepore F, . Behavioral evidence for a functional link between low- and mid-level visual perception in the autism spectrum. Neuropsychologia. 2015 Oct;77:380–6. doi: 10.1016/j.neuropsychologia.2015.09.022. X-126384775
4035 Perry A, Isaacs B. Validity of the Family Quality of Life Survey-2006. J Appl Res Intellect Disabil. 2015 Nov;28(6):584–8. doi: 10.1111/jar.12141. X-125914221
4036 Perry A, Levy-Gigi E, Richter-Levin G, . Interpersonal distance and social anxiety in autistic spectrum disorders: A behavioral and ERP study. Soc Neurosci. 2015 Aug;10(4):354–65. doi: 10.1080/17470919.2015.1010740. X-125666260
4037 Petasecca M, Alhujaili S, Aldosari AH, . Angular independent silicon detector for dosimetry in external beam radiotherapy. Med Phys. 2015 Aug;42(8):4708–18. doi: 10.1118/1.4926778. X-126233198
4038 Peters SM, Pothuizen HH, Spruijt BM. Ethological concepts enhance the translational value of animal models. Eur J Pharmacol. 2015 Jul 15;759:42–50. doi: 10.1016/j.ejphar.2015.03.043. X-125823814
4039 Peterson D, Mahajan R, Crocetti D, . Left-hemispheric microstructural abnormalities in children with high-functioning autism spectrum disorder. Autism Res. 2015 Feb;8(1):61–72. doi: 10.1002/aur.1413. X-125256103
4040 Peterson J, Reed S, Kenny R, . A Two-Factor Structure within the Systemizing Trait of Autism Differentially Predicts Susceptibility to Lateral and Collinear Flanker Effects. J Vis. 2015 Sep 1;15(12):647. doi: 10.1167/15.12.647. X-1
4041 Petit LM, Girard D, Ganousse-Mazeron S, . Weaning Off Prognosis Factors of Home Parenteral Nutrition for Children with Primary Digestive Disease. J Pediatr Gastroenterol Nutr. 2015 Sep 17 doi: 10.1097/mpg.0000000000000980. X-1
4042 Petrongolo M, DuBard M, Luiselli JK. Effects of an idiosyncratic stimulus on functional analysis of vocal stereotypy in two settings. Dev Neurorehabil. 2015 Jun;18(3):209–12. doi: 10.3109/17518423.2013.869271. X-124354848
4043 Petrova M, Mehrabian-Spasova S, Aarsland D, . Clinical and Neuropsychological Differences between Mild Parkinson’s Disease Dementia and Dementia with Lewy Bodies. Dement Geriatr Cogn Dis Extra. 2015 May–Aug;5(2):212–20. doi: 10.1159/000375363. X-126195977
4044 Peykov S, Berkel S, Schoen M, . Identification and functional characterization of rare SHANK2 variants in schizophrenia. Mol Psychiatry. 2015 Jan 6 doi: 10.1038/mp.2014.172. X-1
4045 Piccoli GB, Postorino V, Cabiddu G, . Children of a lesser god or miracles? An emotional and behavioural profile of children born to mothers on dialysis in Italy: a multicentre nationwide study 2000–12. Nephrol Dial Transplant. 2015 Jul;30(7):1193–202. doi: 10.1093/ndt/gfv127. X-126047633
4046 Pickles A, Harris V, Green J, . Treatment mechanism in the MRC preschool autism communication trial: implications for study design and parent-focussed therapy for children. J Child Psychol Psychiatry. 2015 Feb;56(2):162–70. doi: 10.1111/jcpp.12291. X-1, X-2, X-325039961
4047 Pieron M, Seassau M, Leboyer M, . Accelerated time course of saccadic inhibition of return in individuals with autism spectrum disorders. Exp Brain Res. 2015 Mar;233(3):767–75. doi: 10.1007/s00221-014-4152-1. X-125432625
4048 Pileggi LA, Malcolm-Smith S, Solms M. Investigating the role of social-affective attachment processes in cradling bias: the absence of cradling bias in children with Autism Spectrum Disorders. Laterality. 2015;20(2):154–70. doi: 10.1080/1357650x.2014.948449. X-125131653
4049 Pineda R, Melchior K, Oberle S, . Assessment of Autism Symptoms During the Neonatal Period: Is There Early Evidence of Autism Risk? Am J Occup Ther. 2015 Jul–Aug;69(4):6904220010p1–p11. doi: 10.5014/ajot.2015.015925. X-1
4050 Pisula E, Kawa R, Danielewicz D, . The relationship between temperament and autistic traits in a non-clinical students sample. PLoS One. 2015;10(4):e0124364. doi: 10.1371/journal.pone.0124364. X-125860508
4051 Pivovarciova A, Hnilicova S, Ostatnikova D, . Bio-behavioral model of aggression in autism spectrum disorders-pilot study. Bratisl Lek Listy. 2015;116(12):702–6. X-126924148
4052 Plavnick JB, Kaid T, MacFarland MC. Effects of a School-Based Social Skills Training Program for Adolescents with Autism Spectrum Disorder and Intellectual Disability. J Autism Dev Disord. 2015 Sep;45(9):2674–90. doi: 10.1007/s10803-015-2434-5. X-1, X-3, X-425820638
4053 Poirier N, Vallee-Ouimet J. [The life path of parents and of their children presenting an autism spectrum disorder (ASD)]. Sante Ment Que. 2015 Spring;40(1):203–26. X-126355488
4054 Pokorny JJ, Hatt NV, Colombi C, . The Action Observation System when Observing Hand Actions in Autism and Typical Development. Autism Res. 2015 Jun;8(3):284–96. doi: 10.1002/aur.1445. X-125631917
4055 Polyak A, Kubina RM, Girirajan S. Comorbidity of intellectual disability confounds ascertainment of autism: implications for genetic diagnosis. Am J Med Genet B Neuropsychiatr Genet. 2015 Oct;168(7):600–8. doi: 10.1002/ajmg.b.32338. X-126198689
4056 Polyak A, Rosenfeld JA, Girirajan S. An assessment of sex bias in neurodevelopmental disorders. Genome Med. 2015;7(1):94. doi: 10.1186/s13073-015-0216-5. X-126307204
4057 Poole D, Gowen E, Warren PA, . Investigating visual–tactile interactions over time and space in adults with autism. Journal of Autism and Developmental Disorders. 2015 2015-10-07;45(10):3316–26. doi: http://dx.doi.org/10.1007/s10803-015-2492-8; 2015-26686-001. X-126063447
4058 Posar A, Resca F, Visconti P. Autism according to diagnostic and statistical manual of mental disorders 5(th) edition: The need for further improvements. J Pediatr Neurosci. 2015 Apr–Jun;10(2):146–8. doi: 10.4103/1817-1745.159195. X-126167220
4059 Poslawsky IE, Naber FB, Bakermans-Kranenburg MJ, . Video-feedback Intervention to promote Positive Parenting adapted to Autism (VIPP-AUTI): A randomized controlled trial. Autism. 2015 Jul;19(5):588–603. doi: 10.1177/1362361314537124. X-124919961
4060 Postorino V, Fatta LM, De Peppo L, . Longitudinal comparison between male and female preschool children with autism spectrum disorder. J Autism Dev Disord. 2015 Jul;45(7):2046–55. doi: 10.1007/s10803-015-2366-0. X-125633919
4061 Postorino V, Sanges V, Giovagnoli G, . Clinical differences in children with autism spectrum disorder with and without food selectivity. Appetite. 2015 Sep;92:126–32. doi: 10.1016/j.appet.2015.05.016. X-125998237
4062 Pozo P, Sarria E. Still stressed but feeling better: Well-being in autism spectrum disorder families as children become adults. Autism. 2015 Oct;19(7):805–13. doi: 10.1177/1362361315583191. X-125957298
4063 Prasad H, Rao R. Applying knowledge of autism to brain cancer management: what do we know? Future Oncol. 2015;11(13):1847–50. doi: 10.2217/fon.15.93. X-126161920
4064 Prather AA, Epel ES, Arenander J, . Longevity factor klotho and chronic psychological stress. Transl Psychiatry. 2015;5:e585. doi: 10.1038/tp.2015.81. X-126080320
4065 Prayson RA, Gales JM. Coexistent ganglioglioma, focal cortical dysplasia, and hippocampal sclerosis (triple pathology) in chronic epilepsy. Ann Diagn Pathol. 2015 Oct;19(5):310–3. doi: 10.1016/j.anndiagpath.2015.07.003. X-126235882
4066 Prilutsky D, Kho AT, Palmer NP, . Gene expression analysis in Fmr1KO mice identifies an immunological signature in brain tissue and mGluR5-related signaling in primary neuronal cultures. Mol Autism. 2015;6:66. doi: 10.1186/s13229-015-0061-9. X-126697163
4067 Pritchard AE, Kalback S, McCurdy M, . Executive functions among youth with Down Syndrome and co-existing neurobehavioural disorders. J Intellect Disabil Res. 2015 Sep 15 doi: 10.1111/jir.12217. X-1
4068 Provenzano G, Pangrazzi L, Poli A, . Immunohistochemical visualization of hippocampal neuron activity after spatial learning in a mouse model of neurodevelopmental disorders. J Vis Exp. 2015(99):e52919. doi: 10.3791/52919. X-125992917
4069 Puangpetch A, Suwannarat P, Chamnanphol M, . Significant Association of HLA-B Alleles and Genotypes in Thai Children with Autism Spectrum Disorders: A Case-Control Study. Dis Markers. 2015;2015:724935. doi: 10.1155/2015/724935. X-126819491
4070 Pugliese CE, Anthony L, Strang JF, . Increasing adaptive behavior skill deficits from childhood to adolescence in autism spectrum disorder: role of executive function. J Autism Dev Disord. 2015 Jun;45(6):1579–87. doi: 10.1007/s10803-014-2309-1. X-125398602
4071 Pugliese CE, Anthony LG, Strang JF, . Longitudinal Examination of Adaptive Behavior in Autism Spectrum Disorders: Influence of Executive Function. J Autism Dev Disord. 2015 Sep 9 doi: 10.1007/s10803-015-2584-5. X-1
4072 Pugliese CE, Fritz MS, White SW. The role of anger rumination and autism spectrum disorder-linked perseveration in the experience of aggression in the general population. Autism. 2015 Aug;19(6):704–12. doi: 10.1177/1362361314548731. X-125212211
4073 Pugliese CE, Kenworthy L, Bal VH, . Replication and Comparison of the Newly Proposed ADOS-2, Module 4 Algorithm in ASD Without ID: A Multi-site Study. J Autism Dev Disord. 2015 Sep 18 doi: 10.1007/s10803-015-2586-3. X-1
4074 Puig-Alcaraz C, Fuentes-Albero M, Calderon J, . Increased homocysteine levels correlate with the communication deficit in children with autism spectrum disorder. Psychiatry Res. 2015 Oct 30;229(3):1031–7. doi: 10.1016/j.psychres.2015.05.021. X-126070768
4075 Pulcini CD, Perrin JM, Houtrow AJ, . Examining Trends and Coexisting Conditions Among Children Qualifying for SSI Under ADHD, ASD, and ID. Acad Pediatr. 2015 Jul–Aug;15(4):439–43. doi: 10.1016/j.acap.2015.05.002. X-126142070
4076 Purkayastha P, Malapati A, Yogeeswari P, . A Review on GABA/Glutamate Pathway for Therapeutic Intervention of ASD and ADHD. Curr Med Chem. 2015 Feb 9. X-1, X-2
4077 Pusponegoro HD, Ismael S, Firmansyah A, . Gluten and casein supplementation does not increase symptoms in children with autism spectrum disorder. Acta Paediatr. 2015 Nov;104(11):e500–e5. doi: 10.1111/apa.13108.26148018
4078 Qin L, Dai X. [Effect of sulindac on improving autistic behaviors in rats]. Nan Fang Yi Ke Da Xue Xue Bao. 2015 Aug;35(8):1162–5. X-126277514
4079 Qin M, Huang T, Kader M, . R-Baclofen Reverses a Social Behavior Deficit and Elevated Protein Synthesis in a Mouse Model of Fragile X Syndrome. Int J Neuropsychopharmacol. 2015 Jul;18(9) doi: 10.1093/ijnp/pyv034. X-1
4080 Qin M, Zeidler Z, Moulton K, . Endocannabinoid-mediated improvement on a test of aversive memory in a mouse model of fragile X syndrome. Behav Brain Res. 2015 Sep 15;291:164–71. doi: 10.1016/j.bbr.2015.05.003. X-125979787
4081 Quinlan CA, McVeigh KH, Driver CR, . Parental Age and Autism Spectrum Disorders Among New York City Children 0–36 Months of Age. Matern Child Health J. 2015 Aug;19(8):1783–90. doi: 10.1007/s10995-015-1692-3. X-125776271
4082 Radley KC, Ford WB, McHugh MB, . Brief Report: Use of Superheroes Social Skills to Promote Accurate Social Skill Use in Children with Autism Spectrum Disorder. J Autism Dev Disord. 2015 Sep;45(9):3048–54. doi: 10.1007/s10803-015-2442-5. X-3, X-425841884
4083 Rahko JS, Vuontela VA, Carlson S, . Attention and Working Memory in Adolescents with Autism Spectrum Disorder: A Functional MRI Study. Child Psychiatry Hum Dev. 2015 Sep 1 doi: 10.1007/s10578-015-0583-6. X-1
4084 Rahkonen P, Lano A, Pesonen AK, . Atypical sensory processing is common in extremely low gestational age children. Acta Paediatr. 2015 May;104(5):522–8. doi: 10.1111/apa.12911. X-125620288
4085 Rana P, Mishra D. Quality of life of unaffected siblings of children with chronic neurological disorders. Indian J Pediatr. 2015 Jun;82(6):545–8. doi: 10.1007/s12098-014-1672-4. X-125640066
4086 Randall M, Sciberras E, Brignell A, . Autism spectrum disorder: Presentation and prevalence in a nationally representative Australian sample. Aust N Z J Psychiatry. 2015 Aug 17 doi: 10.1177/0004867415595287. X-1
4087 Randel A, Adlof S, Klusek J, . Teaching reading to youth with fragile X syndrome: Should phonemic awareness and phonics instruction be used? EBP Briefs. 2015 Mar;9(6):47–61. X-126500715
4088 Rane P, Cochran D, Hodge SM, . Connectivity in Autism: A Review of MRI Connectivity Studies. Harv Rev Psychiatry. 2015 Jul–Aug;23(4):223–44. doi: 10.1097/hrp.0000000000000072. X-126146755
4089 Rao PA, Raman V, Thomas T, . IQ in Autism: Is there an Alternative Global Cognitive Index? Indian J Psychol Med. 2015 Jan–Mar;37(1):48–52. doi: 10.4103/0253-7176.150819. X-1, X-225722512
4090 Rao VS, Raman V, Mysore AV. Issues related to obtaining intelligence quotient-matched controls in autism research. Indian J Psychol Med. 2015 Apr–Jun;37(2):149–53. doi: 10.4103/0253-7176.155612. X-125969598
4091 Ratcliffe B, Wong M, Dossetor D, . The Association Between Social Skills and Mental Health in School-Aged Children with Autism Spectrum Disorder, With and Without Intellectual Disability. J Autism Dev Disord. 2015 Aug;45(8):2487–96. doi: 10.1007/s10803-015-2411-z. X-125758822
4092 Ratni H, Rogers-Evans M, Bissantz C, . Discovery of highly selective brain-penetrant vasopressin 1a antagonists for the potential treatment of autism via a chemogenomic and scaffold hopping approach. J Med Chem. 2015 Mar 12;58(5):2275–89. doi: 10.1021/jm501745f. X-125654260
4093 Rattaz C, Michelon C, Baghdadli A. Symptom severity as a risk factor for self-injurious behaviours in adolescents with autism spectrum disorders. J Intellect Disabil Res. 2015 Aug;59(8):730–40. doi: 10.1111/jir.12177. X-125583371
4094 Ratto AB, Anthony BJ, Kenworthy L, . Are Non-intellectually Disabled Black Youth with ASD Less Impaired on Parent Report than Their White Peers? J Autism Dev Disord. 2015 Oct 6 doi: 10.1007/s10803-015-2614-3. X-1
4095 Ratto AB, Mesibov GB. Autism spectrum disorders in adolescence and adulthood: Long-term outcomes and relevant issues for treatment and research. Sci China Life Sci. 2015 Oct;58(10):1010–5. doi: 10.1007/s11427-012-4295-x. X-126335732
4096 Rausa VC, Moore DW, Anderson A. Use of video modelling to teach complex and meaningful job skills to an adult with autism spectrum disorder. Dev Neurorehabil. 2015 Aug 24:1–8. doi: 10.3109/17518423.2015.1008150. X-1
4097 Rayner C. Video-based intervention for children with autism: towards improved assessment of pre-requisite imitation skills. Dev Neurorehabil. 2015 Apr;18(2):113–21. doi: 10.3109/17518423.2014.890959. X-1, X-424649844
4098 Raza S, Harker A, Richards S, . Tactile stimulation improves neuroanatomical pathology but not behavior in rats prenatally exposed to valproic acid. Behav Brain Res. 2015 Apr 1;282:25–36. doi: 10.1016/j.bbr.2014.12.055. X-125557797
4099 Reaven J, Blakeley-Smith A, Beattie TL, . Improving transportability of a cognitive-behavioral treatment intervention for anxiety in youth with autism spectrum disorders: results from a US-Canada collaboration. Autism. 2015 Feb;19(2):211–22. doi: 10.1177/1362361313518124. X-3, X-424463434
4100 Reaven J, Washington L, Moody EJ, . Examining the Relationship Between Parental Anxiety and Treatment Response in Children and Adolescents with Autism Spectrum Disorder and Anxiety. J Autism Dev Disord. 2015 Aug;45(8):2464–73. doi: 10.1007/s10803-015-2410-0. X-1, X-325778837
4101 Reese RM, Braun MJ, Hoffmeier S, . Preliminary Evidence for the Integrated Systems Using Telemedicine. Telemed J E Health. 2015 Jul;21(7):581–7. doi: 10.1089/tmj.2014.0124. X-125898157
4102 Reese RM, Jamison TR, Braun M, . Brief report: use of interactive television in identifying autism in young children: methodology and preliminary data. J Autism Dev Disord. 2015 May;45(5):1474–82. doi: 10.1007/s10803-014-2269-5. X-125331323
4103 Reetzke R, Zou X, Sheng L, . Communicative Development in Bilingually Exposed Chinese Children With Autism Spectrum Disorders. J Speech Lang Hear Res. 2015 Jun;58(3):813–25. doi: 10.1044/2015_jslhr-l-13-0258. X-125679338
4104 Reilly C, Senior J, Murtagh L. ASD, ADHD, mental health conditions and psychopharmacology in neurogenetic syndromes: parent survey. J Intellect Disabil Res. 2015 Apr;59(4):307–18. doi: 10.1111/jir.12147. X-124965264
4105 Rhodes G, Neumann MF, Ewing L, . Reduced set averaging of face identity in children and adolescents with autism. Q J Exp Psychol (Hove). 2015;68(7):1391–403. doi: 10.1080/17470218.2014.981554. X-125510166
4106 Ribeiro DM, Miguel CF, Goyos C. The effects of listener training on discriminative control by elements of compound stimuli in children with disabilities. J Exp Anal Behav. 2015 Jul;104(1):48–62. doi: 10.1002/jeab.161. X-126150348
4107 Rice LM, Wall CA, Fogel A, . Computer-Assisted Face Processing Instruction Improves Emotion Recognition, Mentalizing, and Social Skills in Students with ASD. J Autism Dev Disord. 2015 Jul;45(7):2176–86. doi: 10.1007/s10803-015-2380-2. X-125694364
4108 Rice ML. Specific Language Impairment, Nonverbal IQ, ADHD, ASD, Cochlear Implants, Bilingualism and Dialectal Variants: Defining the boundaries, clarifying clinical conditions and sorting out causes. J Speech Lang Hear Res. 2015 Oct 20 doi: 10.1044/2015_jslhr-l-15-0255. X-1
4109 Rice TR. Postnatal testosterone may be an important mediator of the association between prematurity and male neurodevelopmental disorders: a hypothesis. Int J Adolesc Med Health. 2015 Sep 10 doi: 10.1515/ijamh-2015-0047. X-1
4110 Richard AE, Lajiness-O’Neill R. Visual attention shifting in autism spectrum disorders. J Clin Exp Neuropsychol. 2015 Sep;37(7):671–87. doi: 10.1080/13803395.2015.1042838. X-126156236
4111 Richards C, Jones C, Groves L, . Prevalence of autism spectrum disorder phenomenology in genetic disorders: a systematic review and meta-analysis. Lancet Psychiatry. 2015 Oct;2(10):909–16. doi: 10.1016/s2215-0366(15)00376-4. X-1, X-2, X-326341300
4112 Richdale AL, Baglin CL. Self-report and caregiver-report of sleep and psychopathology in children with high-functioning autism spectrum disorder: A pilot study. Dev Neurorehabil. 2015;18(4):272–9. doi: 10.3109/17518423.2013.829534. X-124087935
4113 Richter J, Henze R, Vomstein K, . Reduced cortical thickness and its association with social reactivity in children with autism spectrum disorder. Psychiatry Res. 2015 Aug 22 doi: 10.1016/j.pscychresns.2015.06.011. X-1
4114 Ricketts J, Dockrell JE, Patel N, . Do children with specific language impairment and autism spectrum disorders benefit from the presence of orthography when learning new spoken words? J Exp Child Psychol. 2015 Jun;134:43–61. doi: 10.1016/j.jecp.2015.01.015. X-1, X-325795987
4115 Ricotti V, Mandy WP, Scoto M, . Neurodevelopmental, emotional, and behavioural problems in Duchenne muscular dystrophy in relation to underlying dystrophin gene mutations. Dev Med Child Neurol. 2015 Sep 14 doi: 10.1111/dmcn.12922. X-1
4116 Rieske RD, Matson JL, Beighley JS, . Comorbid psychopathology rates in children diagnosed with autism spectrum disorders according to the DSM-IV-TR and the proposed DSM-5. Dev Neurorehabil. 2015;18(4):218–23. doi: 10.3109/17518423.2013.790519. X-123869479
4117 Rieth SR, Stahmer AC, Suhrheinrich J, . Examination of the prevalence of stimulus overselectivity in children with ASD. J Appl Behav Anal. 2015 Spring;48(1):71–84. doi: 10.1002/jaba.165. X-125418837
4118 Ring M, Gaigg SB, Bowler DM. Relational Memory Processes in Adults with Autism Spectrum Disorder. Autism Res. 2015 May 7 doi: 10.1002/aur.1493. X-1
4119 Rios C, Costa Andrada B. The changing face of autism in Brazil. Cult Med Psychiatry. 2015 Jun;39(2):213–34. doi: 10.1007/s11013-015-9448-5. X-125842350
4120 Roberts AL, Koenen KC, Lyall K, . Association of autistic traits in adulthood with childhood abuse, interpersonal victimization, and posttraumatic stress. Child Abuse Negl. 2015 Jul;45:135–42. doi: 10.1016/j.chiabu.2015.04.010. X-125957197
4121 Roberts RM, Ejova A, Giallo R, . A controlled trial of the SibworkS group program for siblings of children with special needs. Res Dev Disabil. 2015 Aug–Sep;43–44:21–31. doi: 10.1016/j.ridd.2015.06.002. X-1
4122 Robertson AE, David RSR. The sensory experiences of adults with autism spectrum disorder: A qualitative analysis. Perception. 2015;44(5):569–86.x-126422904
4123 Robinson EB, Neale BM, Hyman SE. Genetic research in autism spectrum disorders. Curr Opin Pediatr. 2015 Sep 18 doi: 10.1097/mop.0000000000000278. X-1
4124 Rodriguez-Lopez J, Carrera N, Arrojo M, . An efficient screening method for simultaneous detection of recurrent copy number variants associated with psychiatric disorders. Clin Chim Acta. 2015 May 20;445:34–40. doi: 10.1016/j.cca.2015.03.013. X-125797897
4125 Roine U, Salmi J, Roine T, . Constrained spherical deconvolution-based tractography and tract-based spatial statistics show abnormal microstructural organization in Asperger syndrome. Mol Autism. 2015;6:4. doi: 10.1186/2040-2392-6-4. X-125874076
4126 Rollins PR, Campbell M, Hoffman RT, . A community-based early intervention program for toddlers with autism spectrum disorders. Autism. 2015 Apr 23 doi: 10.1177/1362361315577217. X-3, X-4
4127 Rommelse N, Langerak I, van der Meer J, . Intelligence May Moderate the Cognitive Profile of Patients with ASD. PLoS One. 2015;10(10):e0138698. doi: 10.1371/journal.pone.0138698. X-126444877
4128 Romski M, Sevcik RA, Barton-Hulsey A, . Early Intervention and AAC: What a Difference 30 Years Makes. Augment Altern Commun. 2015;31(3):181–202. doi: 10.3109/07434618.2015.1064163. X-1, X-2, X-3, X-426153901
4129 Rosales R, Gongola L, Homlitas C. An evaluation of video modeling with embedded instructions to teach implementation of stimulus preference assessments. J Appl Behav Anal. 2015 Spring;48(1):209–14. X-125927112
4130 Rosander C, Hallbook T. Dravet syndrome in Sweden: a population-based study. Dev Med Child Neurol. 2015 Mar 13 doi: 10.1111/dmcn.12709. X-1
4131 Roscoe EM, Schlichenmeyer KJ, Dube WV. Functional analysis of problem behavior: A systematic approach for identifying idiosyncratic variables. J Appl Behav Anal. 2015 Summer;48(2):289–314. doi: 10.1002/jaba.201. X-125930176
4132 Rose S, Wynne R, Frye RE, . Increased susceptibility to ethylmercury-induced mitochondrial dysfunction in a subset of autism lymphoblastoid cell lines. J Toxicol. 2015;2015:573701. doi: 10.1155/2015/573701. X-125688267
4133 Rosenberg A, Patterson JS, Angelaki DE. A computational perspective on autism. Proc Natl Acad Sci U S A. 2015 Jul 28;112(30):9158–65. doi: 10.1073/pnas.1510583112. X-126170299
4134 Rosenbloom R, Mason RA, Wills HP, . Technology Delivered Self-Monitoring Application to Promote Successful Inclusion of an Elementary Student with Autism. Assist Technol. 2015 Jul 7 doi: 10.1080/10400435.2015.1059384. X-1, X-3, X-4
4135 Ross LA, Del Bene VA, Molholm S, . Sex differences in multisensory speech processing in both typically developing children and those on the autism spectrum. Front Neurosci. 2015;9:185. doi: 10.3389/fnins.2015.00185. X-126074757
4136 Rousseau P. Reflections: Neurology And The Humanities. Silvia’s blessing. Neurology. 2015 Jun 9;84(23):2379–80. X-226251863
4137 Rowe MP, Gillespie BM, Harris KR, . Redesigning a General Education Science Course to Promote Critical Thinking. CBE Life Sci Educ. 2015 Fall;14(3)doi: 10.1187/cbe.15-02-0032. X-1
4138 Roy A, Roy M, Deb S, . Are opioid antagonists effective in attenuating the core symptoms of autism spectrum conditions in children: a systematic review. J Intellect Disabil Res. 2015 Apr;59(4):293–306. doi: 10.1111/jir.12122. X-224589346
4139 Roy M, Prox-Vagedes V, Ohlmeier MD, . Beyond childhood: psychiatric comorbidities and social background of adults with Asperger syndrome. Psychiatr Danub. 2015 Mar;27(1):50–9. X-125751431
4140 Rubenstein E, Wiggins LD, Lee LC. A Review of the Differences in Developmental, Psychiatric, and Medical Endophenotypes Between Males and Females with Autism Spectrum Disorder. J Dev Phys Disabil. 2015 Feb;27(1):119–39. doi: 10.1007/s10882-014-9397-x. X-126146472
4141 Rubino T, Zamberletti E, Parolaro D. Endocannabinoids and Mental Disorders. Handb Exp Pharmacol. 2015;231:261–83. doi: 10.1007/978-3-319-20825-1_9. X-126408164
4142 Ruby K, Falvey K, Kulesza RJ. Abnormal neuronal morphology and neurochemistry in the auditory brainstem of Fmr1 knockout rats. Neuroscience. 2015 Sep 10;303:285–98. doi: 10.1016/j.neuroscience.2015.06.061. X-126166728
4143 Rueda JR, Guillen V, Ballesteros J, . L-acetylcarnitine for treating fragile X syndrome. Cochrane Database Syst Rev. 2015;5:Cd010012. doi: 10.1002/14651858.CD010012.pub2. X-1
4144 Ruggieri VL, Arberas CL. [Therapeutic approaches in autism spectrum disorders]. Rev Neurol. 2015 Feb 25;60 Suppl 1:S45–9. X-1, X-225726823
4145 Ruiz-Robledillo N, Bellosta-Batalla M, Moya-Albiol L. Lower cardiovascular reactivity to acute stress in informal caregivers of people with autism spectrum disorder than in non-caregivers: Implications for health outcomes. Int J Psychophysiol. 2015 Oct;98(1):143–50. doi: 10.1016/j.ijpsycho.2015.07.011. X-126226113
4146 Ruiz-Robledillo N, Moya-Albiol L. Lower electrodermal activity to acute stress in caregivers of people with autism spectrum disorder: an adaptive habituation to stress. J Autism Dev Disord. 2015 Feb;45(2):576–88. doi: 10.1007/s10803-013-1996-3. X-124221817
4147 Russo AJ. Decreased plasma myeloperoxidase associated with probiotic therapy in autistic children. Clin Med Insights Pediatr. 2015;9:13–7. doi: 10.4137/CMPed.S17901. X-125674031
4148 Russo-Ponsaran NM, McKown C, Johnson JK, . Social-Emotional Correlates of Early Stage Social Information Processing Skills in Children With and Without Autism Spectrum Disorder. Autism Res. 2015 Oct;8(5):486–96. doi: 10.1002/aur.1463. X-125683488
4149 Rutherford MD, Walsh J, Creighton S. Emotion perception or social cognitive complexity: What drives face processing deficits in autism spectrum disorder? J Vis. 2015 Sep 1;15(12):1223. doi: 10.1167/15.12.1223. X-1
4150 Rutherford MD, Walsh JA, Lee V. Brief Report: Infants Developing with ASD Show a Unique Developmental Pattern of Facial Feature Scanning. J Autism Dev Disord. 2015 Aug;45(8):2618–23. doi: 10.1007/s10803-015-2396-7. X-125703032
4151 Ruzich E, Allison C, Smith P, . Subgrouping siblings of people with autism: Identifying the broader autism phenotype. Autism Res. 2015 Sep 2 doi: 10.1002/aur.1544. X-1
4152 Saad K, Abdel-Rahman AA, Elserogy YM, . Vitamin D status in autism spectrum disorders and the efficacy of vitamin D supplementation in autistic children. Nutr Neurosci. 2015 Apr 15 doi: 10.1179/1476830515y.0000000019. X-3
4153 Saad K, Eltayeb AA, Mohamad IL, . A Randomized, Placebo-controlled Trial of Digestive Enzymes in Children with Autism Spectrum Disorders. Clin Psychopharmacol Neurosci. 2015 Aug 31;13(2):188–93. doi: 10.9758/cpn.2015.13.2.188.26243847
4154 Saban-Bezalel R, Mashal N. The effects of intervention on the comprehension of irony and on hemispheric processing of irony in adults with ASD. Neuropsychologia. 2015 Oct;77:233–41. doi: 10.1016/j.neuropsychologia.2015.09.004. X-126359714
4155 Sacco R, Gabriele S, Persico AM. Head circumference and brain size in autism spectrum disorder: A systematic review and meta-analysis. Psychiatry Res. 2015 Sep 28 doi: 10.1016/j.pscychresns.2015.08.016. X-1
4156 Sacks GC, Altarescu G, Guedalia J, . Developmental neuropsychological assessment of 4- to 5-year-old children born following Preimplantation Genetic Diagnosis (PGD): A pilot study. Child Neuropsychol. 2015 Mar 16:1–14. doi: 10.1080/09297049.2015.1014900. X-1
4157 Sacrey LA, Zwaigenbaum L, Bryson S, . Can parents’ concerns predict autism spectrum disorder? A prospective study of high-risk siblings from 6 to 36 months of age. J Am Acad Child Adolesc Psychiatry. 2015 Jun;54(6):470–8. doi: 10.1016/j.jaac.2015.03.014. X-126004662
4158 Sacrey LR, Bennett JA, Zwaigenbaum L. Early Infant Development and Intervention for Autism Spectrum Disorder. J Child Neurol. 2015 Aug 31 doi: 10.1177/0883073815601500. X-1, X-2
4159 Sagiv SK, Kalkbrenner AE, Bellinger DC. Of decrements and disorders: assessing impairments in neurodevelopment in prospective studies of environmental toxicant exposures. Environ Health. 2015;14:8. doi: 10.1186/1476-069x-14-8. X-1, X-225609433
4160 Saiano M, Pellegrino L, Casadio M, . Natural interfaces and virtual environments for the acquisition of street crossing and path following skills in adults with Autism Spectrum Disorders: a feasibility study. J Neuroeng Rehabil. 2015;12:17. doi: 10.1186/s12984-015-0010-z. X-125885279
4161 Saini V, Gregory MK, Uran KJ, . Parametric analysis of response interruption and redirection as treatment for stereotypy. J Appl Behav Anal. 2015 Spring;48(1):96–106. doi: 10.1002/jaba.186. X-125640901
4162 Salcuni S. New frontiers and applications of attachment theory. Front Psychol. 2015;6:273. doi: 10.3389/fpsyg.2015.00273. X-125814972
4163 Saleh M, Nashaat NH, Fahim C, . MRI Surface-Based Brain Morphometry in Egyptian Autistic and Typically Developing Children. Folia Phoniatr Logop. 2015;67(1):29–35. doi: 10.1159/000368962. X-125967922
4164 Salomone E, Beranova S, Bonnet-Brilhault F, . Use of early intervention for young children with autism spectrum disorder across Europe. Autism. 2015 Apr 27 doi: 10.1177/1362361315577218. X-1
4165 Salomone E, Charman T, McConachie H, . Prevalence and correlates of use of complementary and alternative medicine in children with autism spectrum disorder in Europe. Eur J Pediatr. 2015 Oct;174(10):1277–85. doi: 10.1007/s00431-015-2531-7. X-125855095
4166 Salomone E, Charman T, McConachie H, . Child’s verbal ability and gender are associated with age at diagnosis in a sample of young children with ASD in Europe. Child Care Health Dev. 2015 May 28 doi: 10.1111/cch.12261. X-1
4167 Salowitz NMG. Multimodal sensory integration for perception and action in high functioning children with autism spectrum disorder; 2015.
4168 Samango-Sprouse CA, Stapleton EJ, Aliabadi F, . Identification of infants at risk for autism spectrum disorder and developmental language delay prior to 12 months. Autism. 2015 Apr;19(3):327–37. doi: 10.1177/1362361314521329. X-124550549
4169 Samson AC, Hardan AY, Lee IA, . Maladaptive Behavior in Autism Spectrum Disorder: The Role of Emotion Experience and Emotion Regulation. J Autism Dev Disord. 2015 Nov;45(11):3424–32. doi: 10.1007/s10803-015-2388-7. X-125711546
4170 Samson AC, Hardan AY, Podell RW, . Emotion regulation in children and adolescents with autism spectrum disorder. Autism Res. 2015 Feb;8(1):9–18. doi: 10.1002/aur.1387. X-124863869
4171 Samson AC, Wells WM, Phillips JM, . Emotion regulation in autism spectrum disorder: evidence from parent interviews and children’s daily diaries. J Child Psychol Psychiatry. 2015 Aug;56(8):903–13. doi: 10.1111/jcpp.12370. X-1, X-325442191
4172 Samson F, Zeffiro TA, Doyon J, . Speech acquisition predicts regions of enhanced cortical response to auditory stimulation in autism spectrum individuals. J Psychiatr Res. 2015 Sep;68:285–92. doi: 10.1016/j.jpsychires.2015.05.011. X-1, X-226037888
4173 Santangelo G, Vitale C, Picillo M, . Mild Cognitive Impairment in newly diagnosed Parkinson’s disease: A longitudinal prospective study. Parkinsonism Relat Disord. 2015 Oct;21(10):1219–26. doi: 10.1016/j.parkreldis.2015.08.024. X-126321021
4174 Santiago JL, Hanley GP, Moore K, . The Generality of Interview-Informed Functional Analyses: Systematic Replications in School and Home. J Autism Dev Disord. 2015 Oct 3 doi: 10.1007/s10803-015-2617-0. X-1, X-3, X-4
4175 Santomauro D, Sheffield J, Sofronoff K. Depression in Adolescents with ASD: A Pilot RCT of a Group Intervention. J Autism Dev Disord. 2015 Sep 24 doi: 10.1007/s10803-015-2605-4. X-1
4176 Santoso TB, Ito Y, Ohshima N, . Resilience in Daily Occupations of Indonesian Mothers of Children With Autism Spectrum Disorder. Am J Occup Ther. 2015 Sep–Oct;69(5):6905185020p1–8. doi: 10.5014/ajot.2015.017566. X-1
4177 Sarmento S, Costa F, Pereira A, . Attenuation measurements show that the presence of a TachoSil surgical patch will not compromise target irradiation in intra-operative electron radiation therapy or high-dose-rate brachytherapy. Radiat Oncol. 2015;10(1):7. doi: 10.1186/s13014-014-0316-1. X-125572977
4178 Sarrett JC. Custodial Homes, Therapeutic Homes, and Parental Acceptance: Parental Experiences of Autism in Kerala, India and Atlanta, GA USA. Cult Med Psychiatry. 2015 Jun;39(2):254–76. doi: 10.1007/s11013-015-9441-z. X-125772598
4179 Sasaki T, Hashimoto K, Oda Y, . Decreased levels of serum oxytocin in pediatric patients with Attention Deficit/Hyperactivity Disorder. Psychiatry Res. 2015 Aug 30;228(3):746–51. doi: 10.1016/j.psychres.2015.05.029. X-126168929
4180 Sasaki Y, Usami M, Sasayama D, . Concerns expressed by parents of children with pervasive developmental disorders for different time periods of the day: a case-control study. PLoS One. 2015;10(4):e0124692. doi: 10.1371/journal.pone.0124692. X-125898260
4181 Sauce B, Wass C, Netrakanti M, . Heterozygous L1-deficient mice express an autism-like phenotype. Behav Brain Res. 2015 Oct 1;292:432–42. doi: 10.1016/j.bbr.2015.05.040. X-126079769
4182 Saunders BS, Tilford JM, Fussell JJ, . Financial and employment impact of intellectual disability on families of children with autism. Fam Syst Health. 2015 Mar;33(1):36–45. doi: 10.1037/fsh0000102. X-125581557
4183 Say GN, Karabekiroglu K, Babadagi Z, . Maternal stress and perinatal features in autism & attention deficit/ hyperactivity disorder. Pediatr Int. 2015 Sep 4 doi: 10.1111/ped.12822. X-1
4184 Scahill L, McCracken JT, King BH, . Extended-Release Guanfacine for Hyperactivity in Children With Autism Spectrum Disorder. Am J Psychiatry. 2015 Aug 28:appiajp201515010055. doi: 10.1176/appi.ajp.2015.15010055.
4185 Scahill L, Sukhodolsky DG, Anderberg E, . Sensitivity of the modified Children’s Yale-Brown Obsessive Compulsive Scale to detect change: Results from two multi-site trials. Autism. 2015 Apr 16 doi: 10.1177/1362361315574889.
4186 Sceniak MP, Lang M, Enomoto AC, . Mechanisms of Functional Hypoconnectivity in the Medial Prefrontal Cortex of Mecp2 Null Mice. Cereb Cortex. 2015 Feb 7 doi: 10.1093/cercor/bhv002. X-1
4187 Schaaf RC, Cohn ES, Burke J, . Linking Sensory Factors to Participation: Establishing Intervention Goals With Parents for Children With Autism Spectrum Disorder. Am J Occup Ther. 2015 Sep–Oct;69(5):6905185005p1–8. doi: 10.5014/ajot.2015.018036. X-126356657
4188 Schaer M, Kochalka J, Padmanabhan A, . Sex differences in cortical volume and gyrification in autism. Mol Autism. 2015;6:42. doi: 10.1186/s13229-015-0035-y. X-126146534
4189 Schalkwyk G, Peluso F, Qayyum Z, . Varieties of Misdiagnosis in ASD: An Illustrative Case Series. Journal of Autism & Developmental Disorders. 2015;45(4):911–8 8p. doi: 10.1007/s10803-014-2239-y. Language: English. Entry Date: 20150324. Revision Date: 20150710. Publication Type: Journal Article. X-125218849
4190 Scharoun SM, Bryden PJ. Is strength of handedness reliable over repeated testing? An examination of typical development and autism spectrum disorder. Front Psychol. 2015;6:17. doi: 10.3389/fpsyg.2015.00017. X-125691875
4191 Scheeren AM, Banerjee R, Koot HM, . Self-Presentation and the Role of Perspective Taking and Social Motivation in Autism Spectrum Disorder. J Autism Dev Disord. 2015 Sep 25 doi: 10.1007/s10803-015-2610-7. X-1
4192 Schenkelberg MA, Rosenkranz RR, Milliken GA, . Social Environmental Influences on Physical Activity of Children With Autism Spectrum Disorders. J Phys Act Health. 2015 May;12(5):636–41. doi: 10.1123/jpah.2013-0312. X-125109324
4193 Schieve LA, Clayton HB, Durkin MS, . Comparison of Perinatal Risk Factors Associated with Autism Spectrum Disorder (ASD), Intellectual Disability (ID), and Co-occurring ASD and ID. J Autism Dev Disord. 2015 Aug;45(8):2361–72. doi: 10.1007/s10803-015-2402-0. X-125739693
4194 Schieve LA, Fountain C, Boulet SL, . Does Autism Diagnosis Age or Symptom Severity Differ Among Children According to Whether Assisted Reproductive Technology was Used to Achieve Pregnancy? J Autism Dev Disord. 2015 Sep;45(9):2991–3003. doi: 10.1007/s10803-015-2462-1. X-125997596
4195 Schlenz AM, Carpenter LA, Bradley C, . Age Differences in Emergency Department Visits and Inpatient Hospitalizations in Preadolescent and Adolescent Youth with Autism Spectrum Disorders. J Autism Dev Disord. 2015 Aug;45(8):2382–91. doi: 10.1007/s10803-015-2405-x. X-125739694
4196 Schlichenmeyer KJ, Dube WV, Vargas-Irwin M. Stimulus Fading and Response Elaboration in Differential Reinforcement for Alternative Behavior. Behav Interv. 2015 Feb;30(1):51–64. doi: 10.1002/bin.1402. X-1, X-3, X-425844032
4197 Schlosser RW, Koul RK. Speech Output Technologies in Interventions for Individuals with Autism Spectrum Disorders: A Scoping Review. Augment Altern Commun. 2015 Jul 14:1–25. doi: 10.3109/07434618.2015.1063689. X-1, X-2, X-3
4198 Schmeck K. [Pros and cons of antipsychotics in children and adolescents]. Praxis (Bern 1994). 2015 Aug 5;104(16):859–64. doi: 10.1024/1661-8157/a002089. X-126242421
4199 Schmidt C. Mental health: thinking from the gut. Nature. 2015 Feb 26;518(7540):S12–5. doi: 10.1038/518S13a. X-125715275
4200 Schmidt L, Kirchner J, Strunz S, . Psychosocial Functioning and Life Satisfaction in Adults With Autism Spectrum Disorder Without Intellectual Impairment. J Clin Psychol. 2015 Sep 25 doi: 10.1002/jclp.22225. X-1
4201 Schmitz EA, Banerjee R, Pouw LBC, . Better to be equal? Challenges to equality for cognitively able children with autism spectrum disorders in a social decision game. Autism: The International Journal of Research & Practice. 2015;19(2):178–86 9p. doi: 10.1177/1362361313516547. Language: English. Entry Date: 20150130. Revision Date: 20150710. Publication Type: Journal Article. X-124523411
4202 Schmock H, Vangkilde A, Larsen KM, . The Danish 22q11 research initiative. BMC Psychiatry. 2015;15(1):220. doi: 10.1186/s12888-015-0594-7. X-126384214
4203 Schneider I, Regenbogen C, Kohn N, . Reduced Responsiveness to Social Provocation in Autism Spectrum Disorder. Autism Res. 2015 Jun;8(3):297–306. doi: 10.1002/aur.1446. X-125603913
4204 Schreibman L, Dawson G, Stahmer AC, . Naturalistic Developmental Behavioral Interventions: Empirically Validated Treatments for Autism Spectrum Disorder. J Autism Dev Disord. 2015 Aug;45(8):2411–28. doi: 10.1007/s10803-015-2407-8. X-1, X-225737021
4205 Schunke O, Schottle D, Vettorazzi E, . Mirror me: Imitative responses in adults with autism. Autism. 2015 Mar 13 doi: 10.1177/1362361315571757. X-1
4206 Schuwerk T, Vuori M, Sodian B. Implicit and explicit Theory of Mind reasoning in autism spectrum disorders: the impact of experience. Autism. 2015 May;19(4):459–68. doi: 10.1177/1362361314526004. X-124627427
4207 Searles Quick VB, Davis JM, Olincy A, . DUF1220 copy number is associated with schizophrenia risk and severity: implications for understanding autism and schizophrenia as related diseases. Transl Psychiatry. 2015;5:e697. doi: 10.1038/tp.2015.192. X-126670282
4208 Segal-Gavish H, Karvat G, Barak N, . Mesenchymal Stem Cell Transplantation Promotes Neurogenesis and Ameliorates Autism Related Behaviors in BTBR Mice. Autism Res. 2015 Aug 10 doi: 10.1002/aur.1530. X-1
4209 Segar DJ, Chodakiewitz YG, Torabi R, . Deep brain stimulation for the obsessive-compulsive and Tourette-like symptoms of Kleefstra syndrome. Neurosurg Focus. 2015 Jun;38(6):E12. doi: 10.3171/2015.3.focus1528. X-1
4210 Segura M, Pedreno C, Obiols J, . Neurotrophin blood-based gene expression and social cognition analysis in patients with autism spectrum disorder. Neurogenetics. 2015 Apr;16(2):123–31. doi: 10.1007/s10048-014-0434-9. X-125535174
4211 Sekine K, Matsune S, Shiiba K, . Treatment of nostril and nasal stenosis due to facial burn using a self-expandable metallic esophageal stent. Auris Nasus Larynx. 2015 Aug;42(4):348–52. doi: 10.1016/j.anl.2015.02.013. X-125748514
4212 Selim ME, Abd-Elhakim YM, Al-Ayadhi LY. Pancreatic response to gold nanoparticles includes decrease of oxidative stress and inflammation in autistic diabetic model. Cell Physiol Biochem. 2015;35(2):586–600. doi: 10.1159/000369721. X-125612738
4213 Selles RR, Arnold EB, Phares V, . Cognitive-behavioral therapy for anxiety in youth with an autism spectrum disorder: A follow-up study. Autism. 2015 Jul;19(5):613–21. doi: 10.1177/1362361314537912. X-1, X-324923895
4214 Senju A, Vernetti A, Ganea N, . Early Social Experience Affects the Development of Eye Gaze Processing. Curr Biol. 2015 Dec 7;25(23):3086–91. doi: 10.1016/j.cub.2015.10.019. X-126752077
4215 Serret S, Thummler S, Dor E, . Lithium as a rescue therapy for regression and catatonia features in two SHANK3 patients with autism spectrum disorder: case reports. BMC Psychiatry. 2015;15:107. doi: 10.1186/s12888-015-0490-1. X-125947967
4216 Shaaya EA, Pollack SF, Boronat S, . Gastrointestinal problems in 15q duplication syndrome. Eur J Med Genet. 2015 Mar;58(3):191–3. doi: 10.1016/j.ejmg.2014.12.012. X-125573720
4217 Shafritz KM, Bregman JD, Ikuta T, . Neural systems mediating decision-making and response inhibition for social and nonsocial stimuli in autism. Prog Neuropsychopharmacol Biol Psychiatry. 2015 Jul 3;60:112–20. doi: 10.1016/j.pnpbp.2015.03.001. X-125765593
4218 Shao EH, Liolios V, Lindfield D, . Topical Adrenaline (1: 1000) for the Management of Severe Tarsal Conjunctival Chemosis. Ophthal Plast Reconstr Surg. 2015 Jul–Aug;31(4):e115–6. doi: 10.1097/iop.0000000000000143. X-1
4219 Shapira I, Sequeira JM, Quadros EV. Folate receptor autoantibodies in pregnancy related complications. Birth Defects Res A Clin Mol Teratol. 2015 Sep 21 doi: 10.1002/bdra.23436. X-1, X-3
4220 Shapiro EG, Nestrasil I, Ahmed A, . Quantifying behaviors of children with Sanfilippo syndrome: the Sanfilippo Behavior Rating Scale. Mol Genet Metab. 2015 Apr;114(4):594–8. doi: 10.1016/j.ymgme.2015.02.008. X-125770355
4221 Sharda M, Midha R, Malik S, . Fronto-temporal connectivity is preserved during sung but not spoken word listening, across the autism spectrum. Autism Res. 2015 Apr;8(2):174–86. doi: 10.1002/aur.1437. X-1, X-325377165
4222 Sharer EA, Mostofsky SH, Pascual-Leone A, . Isolating Visual and Proprioceptive Components of Motor Sequence Learning in ASD. Autism Res. 2015 Oct 7 doi: 10.1002/aur.1537. X-1
4223 Sharma R, Agarwal A, Rohra VK, . Effects of increased paternal age on sperm quality, reproductive outcome and associated epigenetic risks to offspring. Reprod Biol Endocrinol. 2015;13:35. doi: 10.1186/s12958-015-0028-x. X-125928123
4224 Sharp RA, Mudford OC, Elliffe D. Representativeness of direct observations selected using a work-sampling equation. J Appl Behav Anal. 2015 Spring;48(1):153–66. doi: 10.1002/jaba.193. X-125754895
4225 Shattuck PT, Roux AM. Commentary on employment supports research. Autism. 2015 Feb;19(2):246–7. doi: 10.1177/1362361313518996. X-124449605
4226 Sheehan R, Hassiotis A, Walters K, . Mental illness, challenging behaviour, and psychotropic drug prescribing in people with intellectual disability: UK population based cohort study. Bmj. 2015;351:h4326. doi: 10.1136/bmj.h4326. X-126330451
4227 Shen Y, Xun G, Guo H, . Association and gene-gene interactions study of reelin signaling pathway related genes with autism in the Han Chinese population. Autism Res. 2015 Aug 19 doi: 10.1002/aur.1540. X-1
4228 Shi L, Zhou Y, Ou J, . Different visual preference patterns in response to simple and complex dynamic social stimuli in preschool-aged children with autism spectrum disorders. PLoS One. 2015;10(3):e0122280. doi: 10.1371/journal.pone.0122280. X-125781170
4229 Shic F, Smith D, Horsburgh B, . Catalysts for Change: The Role of Small Business Funders in the Creation and Dissemination of Innovation. J Autism Dev Disord. 2015 Dec;45(12):3900–4. doi: 10.1007/s10803-015-2636-x. X-126481385
4230 Shield A, Meier RP, Tager-Flusberg H. The Use of Sign Language Pronouns by Native-Signing Children with Autism. J Autism Dev Disord. 2015 Jul;45(7):2128–45. doi: 10.1007/s10803-015-2377-x. X-125643865
4231 Shigemori T, Sakai A, Takumi T, . Altered Microglia in the Amygdala Are Involved in Anxiety-related Behaviors of a Copy Number Variation Mouse Model of Autism. J Nippon Med Sch. 2015;82(2):92–9. doi: 10.1272/jnms.82.92. X-125959200
4232 Shiozawa BJ. It’s About Time for Autism Reform Legislation in Utah. J Autism Dev Disord. 2015 May;45(5):1495–6. doi: 10.1007/s10803-014-2302-8. X-125395093
4233 Shire SY, Goods K, Shih W, . Parents’ Adoption of Social Communication Intervention Strategies: Families Including Children with Autism Spectrum Disorder Who are Minimally Verbal. J Autism Dev Disord. 2015 Jun;45(6):1712–24. doi: 10.1007/s10803-014-2329-x. X-325475363
4234 Shmaya Y, Eilat-Adar S, Leitner Y, . Nutritional deficiencies and overweight prevalence among children with autism spectrum disorder. Res Dev Disabil. 2015 Mar;38:1–6. doi: 10.1016/j.ridd.2014.11.020. X-125532026
4235 Shubrata KS, Sinha S, Seshadri SP, . Childhood autism spectrum disorders with and without epilepsy: clinical implications. J Child Neurol. 2015 Mar;30(4):476–82. doi: 10.1177/0883073814540521. X-125038126
4236 Shultz SR, Aziz NA, Yang L, . Intracerebroventricular injection of propionic acid, an enteric metabolite implicated in autism, induces social abnormalities that do not differ between seizure-prone (FAST) and seizure-resistant (SLOW) rats. Behav Brain Res. 2015 Feb 1;278:542–8. doi: 10.1016/j.bbr.2014.10.050. X-125446754
4237 Siegel M, Smith KA, Mazefsky C, . The autism inpatient collection: methods and preliminary sample description. Mol Autism. 2015;6:61. doi: 10.1186/s13229-015-0054-8. X-126557975
4238 Silva D, Houghton S, Hagemann E, . Child attention deficit hyperactive disorder co morbidities on family stress: effect of medication. Community Ment Health J. 2015 Apr;51(3):347–53. doi: 10.1007/s10597-014-9770-3. X-125154408
4239 Silverman JL, Gastrell PT, Karras MN, . Cognitive abilities on transitive inference using a novel touchscreen technology for mice. Cereb Cortex. 2015 May;25(5):1133–42. doi: 10.1093/cercor/bht293. X-124293564
4240 Silverman JL, Pride MC, Hayes JE, . GABAB Receptor Agonist R-Baclofen Reverses Social Deficits and Reduces Repetitive Behavior in Two Mouse Models of Autism. Neuropsychopharmacology. 2015 Aug;40(9):2228–39. doi: 10.1038/npp.2015.66. X-125754761
4241 Simberlund J, Ferretti CJ, Hollander E. Mesenchymal stem cells in autism spectrum and neurodevelopmental disorders: pitfalls and potential promises. World J Biol Psychiatry. 2015 Jul 31:1–8. X-1, X-2
4242 Simmons ES, Paul R, Shic F. Brief Report: A Mobile Application to Treat Prosodic Deficits in Autism Spectrum Disorder and Other Communication Impairments: A Pilot Study. J Autism Dev Disord. 2015 Sep 2 doi: 10.1007/s10803-015-2573-8. X-1, X-3
4243 Simut RE, Vanderfaeillie J, Peca A, . Children with Autism Spectrum Disorders Make a Fruit Salad with Probo, the Social Robot: An Interaction Study. J Autism Dev Disord. 2015 Aug 25 doi: 10.1007/s10803-015-2556-9. X-1
4244 Singer A, Ravi R. Complementary and alternative treatments for autism part 2: identifying and avoiding non-evidence-based treatments. AMA J Ethics. 2015 Apr;17(4):375–80. doi: 10.1001/journalofethics.2015.17.4.sect2-1504. X-125901708
4245 Singer L. Thoughts about sex and gender differences from the next generation of autism scientists. Mol Autism. 2015;6:52. doi: 10.1186/s13229-015-0046-8. X-126388981
4246 Singh HN, Rajeswari MR. Role of long purine stretches in controlling the expression of genes associated with neurological disorders. Gene. 2015 Nov 10;572(2):175–83. doi: 10.1016/j.gene.2015.07.007. X-126149656
4247 Sinha S, McGovern RA, Sheth SA. Deep brain stimulation for severe autism: from pathophysiology to procedure. Neurosurg Focus. 2015 Jun;38(6):E3. doi: 10.3171/2015.3.focus1548. X-1, X-3
4248 Sizoo BB, van der Gaag RJ, van den Brink W. Temperament and character as endophenotype in adults with autism spectrum disorders or attention deficit/hyperactivity disorder. Autism. 2015 May;19(4):400–8. doi: 10.1177/1362361314522352. X-124535690
4249 Skewes JC, Jegindo EM, Gebauer L. Perceptual inference and autistic traits. Autism. 2015 Apr;19(3):301–7. doi: 10.1177/1362361313519872. X-124523412
4250 Skinner HJ, Walther RB, Dolwick MF, . Management of obstructive sleep apnea in a developmentally delayed pediatric patient with aggressive behavior and Pierre Robin sequence. J Clin Sleep Med. 2015;11(2):181–3. doi: 10.5664/jcsm.4470. X-125580604
4251 Skokauskas N, Frodl T. Overlap between Autism Spectrum Disorder and Bipolar Affective Disorder. Psychopathology. 2015;48(4):209–16. doi: 10.1159/000435787. X-126278909
4252 Skorich DP, May AR, Talipski LA, . Is Social Categorization the Missing Link Between Weak Central Coherence and Mental State Inference Abilities in Autism? Preliminary Evidence from a General Population Sample. J Autism Dev Disord. 2015 Oct 5 doi: 10.1007/s10803-015-2623-2. X-1
4253 Slocum SK, Vollmer TR. A comparison of positive and negative reinforcement for compliance to treat problem behavior maintained by escape. J Appl Behav Anal. 2015 Sep;48(3):563–74. doi: 10.1002/jaba.216. X-1, X-3, X-425969379
4254 Small BL. Discovery and Development of Pyridine-bis(imine) and Related Catalysts for Olefin Polymerization and Oligomerization. Acc Chem Res. 2015 Sep 15;48(9):2599–611. doi: 10.1021/acs.accounts.5b00252. X-126267011
4255 Small DM, Pelphrey KA. Autism spectrum disorder: sniffing out a new biomarker. Curr Biol. 2015 Aug 3;25(15):R674–6. doi: 10.1016/j.cub.2015.06.050. X-1, X-226241147
4256 Smith D, Ropar D, Allen HA. Visual integration in autism. Frontiers in Human Neuroscience. 2015 2015-09-09;9; 2015-35634-001. X-125667571
4257 Smith IM, Flanagan HE, Garon N, . Effectiveness of community-based early intervention based on pivotal response treatment. J Autism Dev Disord. 2015 Jun;45(6):1858–72. doi: 10.1007/s10803-014-2345-x. X-1, X-325563454
4258 Smith MJ, Fleming MF, Wright MA, . Brief Report: Vocational Outcomes for Young Adults with Autism Spectrum Disorders at Six Months After Virtual Reality Job Interview Training. J Autism Dev Disord. 2015 Oct;45(10):3364–9. doi: 10.1007/s10803-015-2470-1. X-125986176
4259 Smith Roley S, Mailloux Z, Parham LD, . Sensory Integration and Praxis Patterns in Children With Autism. American Journal of Occupational Therapy. 2015;69(1):1–8 p. doi: 10.5014/ajot.2015.012476. Language: English. Entry Date: 20150110. Revision Date: 20150819. Publication Type: Journal Article. X-1
4260 Smith T, Iadarola S. Evidence Base Update for Autism Spectrum Disorder. J Clin Child Adolesc Psychol. 2015 Nov–Dec;44(6):897–922. doi: 10.1080/15374416.2015.1077448. X-226430947
4261 Smith T, Klorman R, Mruzek DW. Predicting Outcome of Community-Based Early Intensive Behavioral Intervention for Children with Autism. J Abnorm Child Psychol. 2015 Oct;43(7):1271–82. doi: 10.1007/s10802-015-0002-2. X-1, X-325778537
4262 Smith T, Sharp S, Manzardo AM, . Pharmacogenetics informed decision making in adolescent psychiatric treatment: a clinical case report. Int J Mol Sci. 2015;16(3):4416–28. doi: 10.3390/ijms16034416. X-1, X-3, X-425710722
4263 Smoot Reinert S, Jackson K, Bigelow K. Using Posturography to Examine the Immediate Effects of Vestibular Therapy for Children with Autism Spectrum Disorders: A Feasibility Study. Phys Occup Ther Pediatr. 2015 Aug 19:1–16. doi: 10.3109/01942638.2014.975313. X-4
4264 Sniezyk CJ, Zane TL. Investigating the effects of sensory integration therapy in decreasing stereotypy. Focus on Autism and Other Developmental Disabilities. 2015 2015-12-09;30(1):13–22. doi: http://dx.doi.org/10.1177/1088357614525663; 2015-06965-002. X-1, X-3, X-4
4265 So WC, Lui M, Wong TK, . The use of hand gestures to communicate about nonpresent objects in mind among children with autism spectrum disorder. J Speech Lang Hear Res. 2015 Apr;58(2):373–82. doi: 10.1044/2015_jslhr-l-14-0213. X-125785685
4266 So WC, Wong MK, Lui M, . The development of co-speech gesture and its semantic integration with speech in 6- to 12-year-old children with autism spectrum disorders. Autism. 2015 Nov;19(8):956–68. doi: 10.1177/1362361314556783. X-125488001
4267 Sobotka SA, Francis A, Vander Ploeg Booth K. Associations of family characteristics with perceptions of care among parents of children with autism. Child Care Health Dev. 2015 Oct 16 doi: 10.1111/cch.12290. X-1
4268 Solomon M, Frank MJ, Ragland JD, . Feedback-driven trial-by-trial learning in autism spectrum disorders. Am J Psychiatry. 2015 Feb 1;172(2):173–81. doi: 10.1176/appi.ajp.2014.14010036. X-125158242
4269 Solomon O. “But-He’ll Fall!”: Children with Autism, Interspecies Intersubjectivity, and the Problem of ‘Being Social’. Cult Med Psychiatry. 2015 Jun;39(2):323–44. doi: 10.1007/s11013-015-9446-7. X-125926308
4270 Soltanifar A, Akbarzadeh F, Moharreri F, . Comparison of parental stress among mothers and fathers of children with autistic spectrum disorder in Iran. Iran J Nurs Midwifery Res. 2015 Jan–Feb;20(1):93–8. X-125709697
4271 Son JS, Zheng LJ, Rowehl LM, . Comparison of Fecal Microbiota in Children with Autism Spectrum Disorders and Neurotypical Siblings in the Simons Simplex Collection. PLoS One. 2015;10(10):e0137725. doi: 10.1371/journal.pone.0137725. X-126427004
4272 Song J, Bergen SE, Kuja-Halkola R, . Bipolar disorder and its relation to major psychiatric disorders: a family-based study in the Swedish population. Bipolar Disord. 2015 Mar;17(2):184–93. doi: 10.1111/bdi.12242. X-125118125
4273 Song Y, Hakoda Y, Sanefuji W, . Can They See It? The Functional Field of View Is Narrower in Individuals with Autism Spectrum Disorder. PLoS One. 2015;10(7):e0133237. doi: 10.1371/journal.pone.0133237. X-126204121
4274 Soorya LV, Siper PM, Beck T, . Randomized comparative trial of a social cognitive skills group for children with autism spectrum disorder. J Am Acad Child Adolesc Psychiatry. 2015 Mar;54(3):208–16.e1. doi: 10.1016/j.jaac.2014.12.005. X-125721186
4275 Sorensen EM, Bertelsen F, Weikop P, . Hyperactivity and lack of social discrimination in the adolescent Fmr1 knockout mouse. Behav Pharmacol. 2015 Jun 23 doi: 10.1097/fbp.0000000000000152. X-1
4276 Sowden S, Koehne S, Catmur C, . Intact Automatic Imitation and Typical Spatial Compatibility in Autism Spectrum Disorder: Challenging the Broken Mirror Theory. Autism Res. 2015 Jun 26 doi: 10.1002/aur.1511. X-1
4277 Spain D, Blainey SH. Group social skills interventions for adults with high-functioning autism spectrum disorders: A systematic review. Autism. 2015 Oct;19(7):874–86. doi: 10.1177/1362361315587659. X-126045543
4278 Spek AA. [Eating problems in individuals with autism spectrum disorder (ASD) but no intellectual impairment]. Tijdschr Psychiatr. 2015;57(10):749–56. X-126479255
4279 Srinivasan SM, Park IK, Neelly LB, . A comparison of the effects of rhythm and robotic interventions on repetitive behaviors and affective states of children with Autism Spectrum Disorder (ASD). Res Autism Spectr Disord. 2015 Oct 1;18:51–63. doi: 10.1016/j.rasd.2015.07.004. X-126251668
4280 Srinivasjois R, Rao S, Patole S. Probiotic supplementation in children with autism spectrum disorder. Arch Dis Child. 2015 May;100(5):505–6. doi: 10.1136/archdischild-2014-308002. X-2
4281 Staal WG. Autism, DRD3 and repetitive and stereotyped behavior, an overview of the current knowledge. Eur Neuropsychopharmacol. 2015 Sep;25(9):1421–6. doi: 10.1016/j.euroneuro.2014.08.011. X-125224105
4282 Stadnick N, Brookman-Frazee L, Williams KN, . A Pilot Study Examining the Use of the Autism Diagnostic Observation Schedule in Community-Based Mental Health Clinics. Res Autism Spectr Disord. 2015 Dec 1;20:39–46. doi: 10.1016/j.rasd.2015.08.007. X-126379765
4283 Stadnick NA, Stahmer A, Brookman-Frazee L. Preliminary Effectiveness of Project ImPACT: A Parent-Mediated Intervention for Children with Autism Spectrum Disorder Delivered in a Community Program. J Autism Dev Disord. 2015 Jul;45(7):2092–104. doi: 10.1007/s10803-015-2376-y. X-125633920
4284 Stagi P, Galeotti S, Mimmi S, . Continuity of care from child and adolescent to adult mental health services: evidence from a regional survey in Northern Italy. Eur Child Adolesc Psychiatry. 2015 Jul 4 doi: 10.1007/s00787-015-0735-z. X-1
4285 Stahmer AC, Reed S, Lee E, . Training Teachers to use Evidence-Based Practices for Autism: Examining Procedural Implementation fidelity. Psychol Sch. 2015 Feb 1;52(2):181–95. doi: 10.1002/pits.21815. X-125593374
4286 Stanish H, Curtin C, Must A, . Enjoyment, Barriers, and Beliefs About Physical Activity in Adolescents With and Without Autism Spectrum Disorder. Adapt Phys Activ Q. 2015 Oct;32(4):302–17. doi: 10.1123/apaq.2015-0038. X-126485735
4287 Stark KH, Barnes JC, Young ND, . Brief Report: Understanding Crisis Behaviors in Hospitalized Psychiatric Patients with Autism Spectrum Disorder--Iceberg Assessment Interview. J Autism Dev Disord. 2015 Nov;45(11):3468–74. doi: 10.1007/s10803-015-2552-0. X-126324248
4288 Starkstein S, Gellar S, Parlier M, . High rates of parkinsonism in adults with autism. J Neurodev Disord. 2015;7(1):29. doi: 10.1186/s11689-015-9125-6. X-126322138
4289 Steenweg-de Graaff J, Ghassabian A, Jaddoe VW, . Folate concentrations during pregnancy and autistic traits in the offspring. The Generation R Study. Eur J Public Health. 2015 Jun;25(3):431–3. doi: 10.1093/eurpub/cku126. X-125085472
4290 Stefanik P, Olexova L, Krskova L. Increased sociability and gene expression of oxytocin and its receptor in the brains of rats affected prenatally by valproic acid. Pharmacol Biochem Behav. 2015 Apr;131:42–50. doi: 10.1016/j.pbb.2015.01.021. X-125662821
4291 Steiner H, Kertesz Z. Effects of therapeutic horse riding on gait cycle parameters and some aspects of behavior of children with autism. Acta Physiol Hung. 2015 Sep;102(3):324–35. doi: 10.1556/036.102.2015.3.10. X-1, X-326551748
4292 Stendal K, Balandin S. Virtual worlds for people with autism spectrum disorder: a case study in Second Life. Disabil Rehabil. 2015;37(17):1591–8. doi: 10.3109/09638288.2015.1052577. X-126023707
4293 Stephanie D, Julie F. Exploring links between language and cognition in autism spectrum disorders: Complement sentences, false belief, and executive functioning. J Commun Disord. 2015 Mar–Apr;54:15–31. doi: 10.1016/j.jcomdis.2014.12.001. X-125637130
4294 Stewart CR, Sanchez SS, Grenesko EL, . Sensory Symptoms and Processing of Nonverbal Auditory and Visual Stimuli in Children with Autism Spectrum Disorder. J Autism Dev Disord. 2015 Feb 5 doi: 10.1007/s10803-015-2367-z. X-1
4295 Stewart LT. Cell adhesion proteins and the pathogenesis of autism spectrum disorders. J Neurophysiol. 2015 Mar 1;113(5):1283–6. doi: 10.1152/jn.00780.2013. X-124990562
4296 Stewart PA, Hyman SL, Schmidt BL, . Dietary Supplementation in Children with Autism Spectrum Disorders: Common, Insufficient, and Excessive. J Acad Nutr Diet. 2015 Aug;115(8):1237–48. doi: 10.1016/j.jand.2015.03.026. X-126052041
4297 Stiegler LN. Examining the Echolalia Literature: Where Do Speech-Language Pathologists Stand? Am J Speech Lang Pathol. 2015 Jul 10 doi: 10.1044/2015_ajslp-14-0166. X-1, X-2
4298 Stilling RM, Ryan FJ, Hoban AE, . Microbes & neurodevelopment - Absence of microbiota during early life increases activity-related transcriptional pathways in the amygdala. Brain Behav Immun. 2015 Jul 14 doi: 10.1016/j.bbi.2015.07.009. X-1
4299 Stins JF, Emck C, de Vries EM, . Attentional and sensory contributions to postural sway in children with autism spectrum disorder. Gait Posture. 2015 Jul;42(2):199–203. doi: 10.1016/j.gaitpost.2015.05.010. X-126028526
4300 Storch EA, Lewin AB, Collier AB, . A randomized controlled trial of cognitive-behavioral therapy versus treatment as usual for adolescents with autism spectrum disorders and comorbid anxiety. Depress Anxiety. 2015 Mar;32(3):174–81. doi: 10.1002/da.22332. X-125424398
4301 Storch EA, Nadeau JM, Rudy B, . A Case Series of Cognitive-Behavioral Therapy Augmentation of Antidepressant Medication for Anxiety in Children With Autism Spectrum Disorders. Children’s Health Care. 2015;44(2):183–98 16p. doi: 10.1080/02739615.2014.906310. Language: English. Entry Date: 20150424. Revision Date: 20150710. Publication Type: Journal Article. X-3, X-4
4302 Storch EA, Zavrou S, Collier AB, . Preliminary study of family accommodation in youth with autism spectrum disorders and anxiety: Incidence, clinical correlates, and behavioral treatment response. J Anxiety Disord. 2015 Aug;34:94–9. doi: 10.1016/j.janxdis.2015.06.007. X-1, X-326188615
4303 Strauss K, Benvenuto A, Battan B, . Promoting Shared Decision Making to strengthen outcome of young children with Autism Spectrum Disorders: the role of staff competence. Res Dev Disabil. 2015 Mar;38:48–63. doi: 10.1016/j.ridd.2014.11.016. X-125544428
4304 Stuttard L, Beresford B, Clarke S, . A preliminary investigation into the effectiveness of a group-delivered sleep management intervention for parents of children with intellectual disabilities. J Intellect Disabil. 2015 Mar 19 doi: 10.1177/1744629515576610. X-3
4305 Stuttard L, Clarke S, Thomas M, . Replacing home visits with telephone calls to support parents implementing a sleep management intervention: findings from a pilot study and implications for future research. Child Care Health Dev. 2015 Apr 10 doi: 10.1111/cch.12250. X-1, X-4
4306 Suades-Gonzalez E, Gascon M, Guxens M, . Air Pollution and Neuropsychological Development: A Review of the Latest Evidence. Endocrinology. 2015 Oct;156(10):3473–82. doi: 10.1210/en.2015-1403. X-126241071
4307 Suganya V, Geetha A, Sujatha S. Urine proteome analysis to evaluate protein biomarkers in children with autism. Clin Chim Acta. 2015 Oct 23;450:210–9. doi: 10.1016/j.cca.2015.08.015. X-126296899
4308 Suhrheinrich J. A sustainable model for training teachers to use pivotal response training. Autism. 2015 Aug;19(6):713–23. doi: 10.1177/1362361314552200. X-125319208
4309 Sullivan AL, Sadeh S. Psychopharmacological treatment among adolescents with disabilities: Prevalence and predictors in a nationally representative sample. Sch Psychol Q. 2015 Sep;30(3):443–55. doi: 10.1037/spq0000105. X-125528591
4310 Sun F, Oristaglio J, Levy SE, . AHRQ Comparative Effectiveness Technical Briefs. Genetic Testing for Developmental Disabilities, Intellectual Disability, and Autism Spectrum Disorder. Rockville (MD): Agency for Healthcare Research and Quality (US); 2015.
4311 Sun Y. Supercritical Fluid Particle Design of DPI Formulations (Review). Curr Pharm Des. 2015;21(19):2516–42. X-125876911
4312 Sung C, Sanchez J, Kuo HJ, . Gender differences in vocational rehabilitation service predictors of successful competitive employment for transition-aged individuals with autism. J Autism Dev Disord. 2015 Oct;45(10):3204–18. doi: 10.1007/s10803-015-2480-z. X-126060047
4313 Supekar K, Menon V. Sex differences in structural organization of motor systems and their dissociable links with repetitive/restricted behaviors in children with autism. Mol Autism. 2015;6:50. doi: 10.1186/s13229-015-0042-z. X-126347127
4314 Suryadevara M, Handel A, Bonville CA, . Pediatric provider vaccine hesitancy: An under-recognized obstacle to immunizing children. Vaccine. 2015 Nov 27;33(48):6629–34. doi: 10.1016/j.vaccine.2015.10.096. X-126529071
4315 Sussman D, Leung RC, Vogan VM, . The autism puzzle: Diffuse but not pervasive neuroanatomical abnormalities in children with ASD. Neuroimage Clin. 2015;8:170–9. doi: 10.1016/j.nicl.2015.04.008. X-126106541
4316 Sutherland B, Middlebrook N, Kairn T, . A comparison between direct TMR measurements and TMRs calculated from PDDs using BJR Supplement 25 data for flattened and unflattened photon beams. Australas Phys Eng Sci Med. 2015 Sep;38(3):503–7. doi: 10.1007/s13246-015-0359-0. X-126123946
4317 Suzuki K, Kobayashi T, Moriyama K, . [Parenting resilience for rearing a child with autism spectrum disorder: a qualitative study]. No To Hattatsu. 2015 Jul;47(4):283–8. X-126353450
4318 Suzumura S. Quality of life in mothers of preschoolers with high-functioning pervasive developmental disorders. Pediatr Int. 2015 Feb;57(1):149–54. doi: 10.1111/ped.12560. X-125495867
4319 Swain NR, Eadie PA, Prior MR, . Assessing early communication skills at 12 months: a retrospective study of Autism Spectrum Disorder. Int J Lang Commun Disord. 2015 Jul;50(4):488–98. doi: 10.1111/1460-6984.12150. X-125630989
4320 Swanger SA, Mattheyses AL, Gentry EG, . ROCK1 and ROCK2 inhibition alters dendritic spine morphology in hippocampal neurons. Cell Logist. 2015 Oct–Dec;5(4):e1133266. doi: 10.1080/21592799.2015.1133266. X-127054047
4321 Swineford LB, Guthrie W, Thurm A. Convergent and Divergent Validity of the Mullen Scales of Early Learning in Young Children With and Without Autism Spectrum Disorder. Psychol Assess. 2015 Apr 20 doi: 10.1037/pas0000116. X-1
4322 Swinth Y, Tomlin G, Luthman M. Content Analysis of Qualitative Research on Children and Youth With Autism, 1993–2011: Considerations for Occupational Therapy Services. Am J Occup Ther. 2015 Sep–Oct;69(5):6905185030p1–9. doi: 10.5014/ajot.2015.017970. X-1, X-2
4323 Szakacs A, Hallbook T, Tideman P, . Psychiatric comorbidity and cognitive profile in children with narcolepsy with or without association to the H1N1 influenza vaccination. Sleep. 2015 Apr;38(4):615–21. doi: 10.5665/sleep.4582. X-125325473
4324 Tager-Flusberg H. Risk Factors Associated with Language in Autism Spectrum Disorder: Clues to Underlying Mechanisms. J Speech Lang Hear Res. 2015 Oct 20 doi: 10.1044/2015_jslhr-l-15-0146. X-1
4325 Takahashi H, Komatsu S, Nakahachi T, . Relationship of the Acoustic Startle Response and Its Modulation to Emotional and Behavioral Problems in Typical Development Children and Those with Autism Spectrum Disorders. J Autism Dev Disord. 2015 Sep 12 doi: 10.1007/s10803-015-2593-4. X-1
4326 Takai T, Inamoto T, Komura K, . Feasibility of photodynamic diagnosis for challenging TUR- Bt cases including muscle invasive bladder cancer, BCG failure or 2nd-TUR. Asian Pac J Cancer Prev. 2015;16(6):2297–301. X-125824753
4327 Takano T. Role of Microglia in Autism: Recent Advances. Dev Neurosci. 2015;37(3):195–202. doi: 10.1159/000398791. X-125998072
4328 Takeuchi H, Taki Y, Sekiguchi A, . Brain structures in the sciences and humanities. Brain Struct Funct. 2015 Nov;220(6):3295–305. doi: 10.1007/s00429-014-0857-y. X-125079346
4329 Talbott EO, Marshall LP, Rager JR, . Air toxics and the risk of autism spectrum disorder: the results of a population based case-control study in southwestern Pennsylvania. Environ Health. 2015;14:80. doi: 10.1186/s12940-015-0064-1. X-126444407
4330 Talbott MR, Nelson CA, Tager-Flusberg H. Maternal Vocal Feedback to 9-Month-Old Infant Siblings of Children with ASD. Autism Res. 2015 Jul 14 doi: 10.1002/aur.1521. X-1
4331 Talpos JC, Riordan J, Olley J, . Opposing effects of glutamatergic and GABAergic pharmacological manipulations on a visual perception task with relevance to schizophrenia. Psychopharmacology (Berl). 2015 Nov;232(21–22):3967–76. doi: 10.1007/s00213-015-3964-4. X-126014109
4332 Tamasaki A, Saito Y, Ueda R, . Effects of donepezil and serotonin reuptake inhibitor on acute regression during adolescence in Down syndrome. Brain Dev. 2015 Jul 2 doi: 10.1016/j.braindev.2015.06.006. X-1
4333 Tang B, Wang T, Wan H, . Fmr1 deficiency promotes age-dependent alterations in the cortical synaptic proteome. Proc Natl Acad Sci U S A. 2015 Aug 25;112(34):E4697–706. doi: 10.1073/pnas.1502258112. X-126307763
4334 Tang KL, Antshel KM, Fremont WP, . Behavioral and Psychiatric Phenotypes in 22q11.2 Deletion Syndrome. J Dev Behav Pediatr. 2015 Oct;36(8):639–50. doi: 10.1097/dbp.0000000000000210. X-126372046
4335 Tanner K, Hand BN, O’Toole G, . Effectiveness of Interventions to Improve Social Participation, Play, Leisure, and Restricted and Repetitive Behaviors in People With Autism Spectrum Disorder: A Systematic Review. Am J Occup Ther. 2015 Sep–Oct;69(5):6905180010p1–p12. doi: 10.5014/ajot.2015.017806. X-2
4336 Tarazi FI, Sahli ZT, Pleskow J, . Asperger’s syndrome: diagnosis, comorbidity and therapy. Expert Rev Neurother. 2015 Mar;15(3):281–93. doi: 10.1586/14737175.2015.1009898. X-125655905
4337 Tell D, Davidson D. Emotion recognition from congruent and incongruent emotional expressions and situational cues in children with autism spectrum disorder. Autism. 2015 Apr;19(3):375–9. doi: 10.1177/1362361314535676. X-124852752
4338 Ten Eycke K, Müller U. Brief Report: New Evidence for a Social-Specific Imagination Deficit in Children with Autism Spectrum Disorder. Journal of Autism & Developmental Disorders. 2015;45(1):213–20 8p. doi: 10.1007/s10803-014-2206-7. Language: English. Entry Date: 20150109. Revision Date: 20150710. Publication Type: Journal Article. X-125103864
4339 Tessier S, Lambert A, Chicoine M, . Intelligence measures and stage 2 sleep in typically-developing and autistic children. Int J Psychophysiol. 2015 Jul;97(1):58–65. doi: 10.1016/j.ijpsycho.2015.05.003. X-125958790
4340 Tessier S, Lambert A, Scherzer P, . REM sleep and emotional face memory in typically-developing children and children with autism. Biol Psychol. 2015 Sep;110:107–14. doi: 10.1016/j.biopsycho.2015.07.012. X-126219603
4341 Thanos PK, Restif C, O’Rourke JR, . Mouse Social Interaction Test (MoST): a quantitative computer automated analysis of behavior. J Neural Transm (Vienna). 2015 Dec 24 doi: 10.1007/s00702-015-1487-0. X-1, X-2
4342 Theoharides TC, Stewart JM, Panagiotidou S, . Mast cells, brain inflammation and autism. Eur J Pharmacol. 2015 May 1 doi: 10.1016/j.ejphar.2015.03.086. X-1
4343 Thiebaut FI, White SJ, Walsh A, . Does Faux Pas Detection in Adult Autism Reflect Differences in Social Cognition or Decision-Making Abilities? J Autism Dev Disord. 2015 Aug 15 doi: 10.1007/s10803-015-2551-1. X-1
4344 Thienpont L, Verhofstadt M, Van Loon T, . Euthanasia requests, procedures and outcomes for 100 Belgian patients suffering from psychiatric disorders: a retrospective, descriptive study. BMJ Open. 2015;5(7):e007454. doi: 10.1136/bmjopen-2014-007454. X-1
4345 Thoelking J, Sekar Y, Fleckenstein J, . Characterization of a new transmission detector for patient individualized online plan verification and its influence on 6MV x-ray beam characteristics. Z Med Phys. 2015 Aug 21 doi: 10.1016/j.zemedi.2015.08.001. X-1
4346 Thomas MS, Davis R, Karmiloff-Smith A, . The over-pruning hypothesis of autism. Dev Sci. 2015 Apr 6 doi: 10.1111/desc.12303. X-1
4347 Thomas S, Sciberras E, Lycett K, . Physical Functioning, Emotional, and Behavioral Problems in Children With ADHD and Comorbid ASD: A Cross-Sectional Study. J Atten Disord. 2015 May 25 doi: 10.1177/1087054715587096. X-1
4348 Thomeer ML, Smith RA, Lopata C, . Randomized Controlled Trial of Mind Reading and In Vivo Rehearsal for High-Functioning Children with ASD. J Autism Dev Disord. 2015 Jul;45(7):2115–27. doi: 10.1007/s10803-015-2374-0. X-125643864
4349 Thompson JI, Peck CE, Karvelas G, . Temporal processing as a source of altered visual perception in high autistic tendency. Neuropsychologia. 2015 Mar;69:148–53. doi: 10.1016/j.neuropsychologia.2015.01.046. X-125645512
4350 Thomson K, Burnham Riosa P, Weiss JA. Brief Report of Preliminary Outcomes of an Emotion Regulation Intervention for Children with Autism Spectrum Disorder. J Autism Dev Disord. 2015 Nov;45(11):3487–95. doi: 10.1007/s10803-015-2446-1. X-1, X-325877014
4351 Thurman AJ, McDuffie A, Kover ST, . Autism Symptomatology in Boys with Fragile X Syndrome: A Cross Sectional Developmental Trajectories Comparison with Nonsyndromic Autism Spectrum Disorder. J Autism Dev Disord. 2015 Sep;45(9):2816–32. doi: 10.1007/s10803-015-2443-4. X-125904201
4352 Tian D, Stoppel LJ, Heynen AJ, . Contribution of mGluR5 to pathophysiology in a mouse model of human chromosome 16p11.2 microdeletion. Nat Neurosci. 2015 Feb;18(2):182–4. doi: 10.1038/nn.3911. X-125581360
4353 Tilford JM, Payakachat N, Kuhlthau KA, . Treatment for Sleep Problems in Children with Autism and Caregiver Spillover Effects. J Autism Dev Disord. 2015 Nov;45(11):3613–23. doi: 10.1007/s10803-015-2507-5. X-1, X-326126749
4354 Tillmann J, Olguin A, Tuomainen J, . The Effect of Visual Perceptual Load on Auditory Awareness in Autism Spectrum Disorder. J Autism Dev Disord. 2015 Oct;45(10):3297–307. doi: 10.1007/s10803-015-2491-9. X-126043848
4355 Tilot AK, Bebek G, Niazi F, . Neural transcriptome of constitutional Pten dysfunction in mice and its relevance to human idiopathic autism spectrum disorder. Mol Psychiatry. 2015 Mar 10 doi: 10.1038/mp.2015.17. X-1
4356 Timonen-Soivio L, Sourander A, Malm H, . The Association Between Autism Spectrum Disorders and Congenital Anomalies by Organ Systems in a Finnish National Birth Cohort. J Autism Dev Disord. 2015 Oct;45(10):3195–203. doi: 10.1007/s10803-015-2477-7. X-126036648
4357 Tomchek SD, Little LM, Dunn W. Sensory Pattern Contributions to Developmental Performance in Children With Autism Spectrum Disorder. Am J Occup Ther. 2015 Sep–Oct;69(5):6905185040p1–p10. doi: 10.5014/ajot.2015.018044. X-1
4358 Tomlin GS, Swinth Y. Contribution of Qualitative Research to Evidence in Practice for People With Autism Spectrum Disorder. Am J Occup Ther. 2015 Sep–Oct;69(5):6905360010p1–4. doi: 10.5014/ajot.2015.017988. X-1, X-2, X-3
4359 Tomova A, Husarova V, Lakatosova S, . Gastrointestinal microbiota in children with autism in Slovakia. Physiol Behav. 2015 Jan;138:179–87. doi: 10.1016/j.physbeh.2014.10.033. X-125446201
4360 Tomson SN, Schreiner MJ, Narayan M, . Resting state functional MRI reveals abnormal network connectivity in neurofibromatosis 1. Hum Brain Mapp. 2015 Nov;36(11):4566–81. doi: 10.1002/hbm.22937. X-126304096
4361 Tonhajzerova I, Ondrejka I, Mestanik M, . Inflammatory Activity in Autism Spectrum Disorder. Adv Exp Med Biol. 2015;861:93–8. doi: 10.1007/5584_2015_145. X-126022900
4362 Tourian L, LeBoeuf A, Breton JJ, . Treatment Options for the Cardinal Symptoms of Disruptive Mood Dysregulation Disorder. J Can Acad Child Adolesc Psychiatry. 2015 Winter;24(1):41–54. X-126336379
4363 Travers BG, Kana RK, Klinger LG, . Motor learning in individuals with autism spectrum disorder: activation in superior parietal lobule related to learning and repetitive behaviors. Autism Res. 2015 Feb;8(1):38–51. doi: 10.1002/aur.1403. X-125258047
4364 Trembath D, Vivanti G, Iacono T, . Accurate or assumed: visual learning in children with ASD. J Autism Dev Disord. 2015 Oct;45(10):3276–87. doi: 10.1007/s10803-015-2488-4. X-126070275
4365 Trivedi MS, Hodgson NW, Walker SJ, . Epigenetic effects of casein-derived opioid peptides in SH-SY5Y human neuroblastoma cells. Nutr Metab (Lond). 2015;12:54. doi: 10.1186/s12986-015-0050-1. X-126664459
4366 Trivisano M, Specchio N, Vigevano F. Extending the use of stiripentol to other epileptic syndromes: a case of PCDH19-related epilepsy. Eur J Paediatr Neurol. 2015 Mar;19(2):248–50. doi: 10.1016/j.ejpn.2014.11.008. X-125510386
4367 Trontel HG, Duffield TC, Bigler ED, . Mesial temporal lobe and memory function in autism spectrum disorder: an exploration of volumetric findings. J Clin Exp Neuropsychol. 2015;37(2):178–92. doi: 10.1080/13803395.2014.997677. X-125749302
4368 Truong DT, Rendall AR, Castelluccio BC, . Auditory Processing and Morphological Anomalies in Medial Geniculate Nucleus of Cntnap2 Mutant Mice. Behav Neurosci. 2015 Oct 26 doi: 10.1037/bne0000096. X-1
4369 Tsai SJ. Is riluzole a potential therapy for Rett syndrome? Med Hypotheses. 2015 Jul;85(1):76–8. doi: 10.1016/j.mehy.2015.03.025. X-125858436
4370 Tsilioni I, Taliou A, Francis K, . Children with autism spectrum disorders, who improved with a luteolin-containing dietary formulation, show reduced serum levels of TNF and IL-6. Transl Psychiatry. 2015;5:e647. doi: 10.1038/tp.2015.142. X-326418275
4371 Tsuji S, Yuhi T, Furuhara K, . Salivary oxytocin concentrations in seven boys with autism spectrum disorder received massage from their mothers: a pilot study. Front Psychiatry. 2015;6:58. doi: 10.3389/fpsyt.2015.00058. X-3, X-425954210
4372 Tsutiya A, Nishihara M, Goshima Y, . Mouse pups lacking collapsin response mediator protein 4 manifest impaired olfactory function and hyperactivity in the olfactory bulb. Eur J Neurosci. 2015 Sep;42(6):2335–45. doi: 10.1111/ejn.12999. X-126118640
4373 Tudor ME, Walsh CE, Mulder EC, . Pain as a predictor of sleep problems in youth with autism spectrum disorders. Autism. 2015 Apr;19(3):292–300. doi: 10.1177/1362361313518994. X-124497628
4374 Turygin N, Matson JL, Tureck K. The relationship of attention-deficit hyperactivity disorder and autism spectrum disorder to adaptive skills in young children. Dev Neurorehabil. 2015 Oct;18(5):317–21. doi: 10.3109/17518423.2013.846947. X-124303981
4375 Tye C, Farroni T, Volein A, . Autism diagnosis differentiates neurophysiological responses to faces in adults with tuberous sclerosis complex. J Neurodev Disord. 2015;7:33. doi: 10.1186/s11689-015-9129-2. X-126451165
4376 Uchida M, Spencer TJ, Faraone SV, . Adult Outcome of ADHD: An Overview of Results From the MGH Longitudinal Family Studies of Pediatrically and Psychiatrically Referred Youth With and Without ADHD of Both Sexes. J Atten Disord. 2015 Sep 22 doi: 10.1177/1087054715604360. X-1
4377 Ueyama Y. A Bayesian Model of the Uncanny Valley Effect for Explaining the Effects of Therapeutic Robots in Autism Spectrum Disorder. PLoS One. 2015;10(9):e0138642. doi: 10.1371/journal.pone.0138642. X-1, X-2, X-326389805
4378 Ujiie Y, Asai T, Wakabayashi A. The relationship between level of autistic traits and local bias in the context of the McGurk effect. Frontiers in Psychology. 2015 2016-01-06;6 doi: 10.1017/CBO9780511526770 10.1007/s10803-010-1000-4; 2015-55530-001. X-125759672
4379 Ung D, Selles R, Small BJ, . A Systematic Review and Meta-Analysis of Cognitive-Behavioral Therapy for Anxiety in Youth with High-Functioning Autism Spectrum Disorders. Child Psychiatry Hum Dev. 2015 Aug;46(4):533–47. doi: 10.1007/s10578-014-0494-y. X-225246292
4380 Ungar WJ. Next Generation Sequencing and Health Technology Assessment in Autism Spectrum Disorder. J Can Acad Child Adolesc Psychiatry. 2015 Fall;24(2):123–7. X-126379724
4381 Unwin LM, Maybery MT, Murphy A, . A Prospective Ultrasound Study of Prenatal Growth in Infant Siblings of Children With Autism. Autism Res. 2015 Jul 7 doi: 10.1002/aur.1518. X-1
4382 Uppal N, Puri R, Yuk F, . Ultrastructural analyses in the hippocampus CA1 field in Shank3-deficient mice. Mol Autism. 2015;6:41. doi: 10.1186/s13229-015-0036-x. X-126137200
4383 Urbain CM, Pang EW, Taylor MJ. Atypical spatiotemporal signatures of working memory brain processes in autism. Transl Psychiatry. 2015;5:e617. doi: 10.1038/tp.2015.107. X-126261885
4384 Urbano M, Okwara L, Manser P, . A trial of d-cycloserine to treat the social deficit in older adolescents and young adults with autism spectrum disorders. J Neuropsychiatry Clin Neurosci. 2015 Spring;27(2):133–8. doi: 10.1176/appi.neuropsych.13070155. X-125923852
4385 Ure AM, Treyvaud K, Thompson DK, . Neonatal brain abnormalities associated with autism spectrum disorder in children born very preterm. Autism Res. 2015 Oct 7 doi: 10.1002/aur.1558. X-1
4386 Usami M, Iwadare Y, Watanabe K, . A case-control study of the difficulties in daily functioning experienced by children with depressive disorder. J Affect Disord. 2015 Jul 1;179:167–74. doi: 10.1016/j.jad.2015.03.023. X-125863914
4387 Usher LV, Burrows CA, Schwartz CB, . Social Competence with an Unfamiliar Peer in Children and Adolescents with High Functioning Autism: Measurement and Individual Differences. Res Autism Spectr Disord. 2015 Sep 1;17:25–39. doi: 10.1016/j.rasd.2015.05.005. X-126161136
4388 Uzunova G, Pallanti S, Hollander E. Excitatory/inhibitory imbalance in autism spectrum disorders: Implications for interventions and therapeutics. World J Biol Psychiatry. 2015 Oct 15:1–13. doi: 10.3109/15622975.2015.1085597. X-1
4389 Vaiouli P, Grimmet K, Ruich LJ. “Bill is now singing”: joint engagement and the emergence of social communication of three young children with autism. Autism. 2015 Jan;19(1):73–83. doi: 10.1177/1362361313511709. X-3, X-424254638
4390 Valdez C, Scroggs R, Chassen R, . Variation in Dube3a expression affects neurotransmission at the Drosophila neuromuscular junction. Biol Open. 2015;4(7):776–82. doi: 10.1242/bio.20148045. X-125948754
4391 van Asselt-Goverts AE, Embregts PJ, Hendriks AH, . Do social networks differ? Comparison of the social networks of people with intellectual disabilities, people with autism spectrum disorders and other people living in the community. J Autism Dev Disord. 2015 May;45(5):1191–203. doi: 10.1007/s10803-014-2279-3. X-125326258
4392 van Bennekom MJ, Blom RM, Vulink N, . A case of digital hoarding. BMJ Case Rep. 2015;2015 doi: 10.1136/bcr-2015-210814. X-1
4393 van Bon BW, Coe BP, Bernier R, . Disruptive de novo mutations of DYRK1A lead to a syndromic form of autism and ID. Mol Psychiatry. 2015 Feb 24 doi: 10.1038/mp.2015.5. X-1
4394 Van der Hallen R, Chamberlain R, de-Wit L, . The Leuven Embedded Figures Test (L-EFT): Re-embedding the EFT into vision sciences. J Vis. 2015 Sep 1;15(12):336. doi: 10.1167/15.12.336. X-1
4395 van der Meer JM, Hartman CA, Thissen AJ, . How ‘core’ are motor timing difficulties in ADHD? A latent class comparison of pure and comorbid ADHD classes. Eur Child Adolesc Psychiatry. 2015 Jul 8 doi: 10.1007/s00787-015-0734-0. X-1
4396 Van der Paelt S, Warreyn P, Roeyers H. Effect of community interventions on social-communicative abilities of preschoolers with autism spectrum disorder. Dev Neurorehabil. 2015 Aug 24:1–13. doi: 10.3109/17518423.2014.933983. X-1
4397 Van Eylen L, Boets B, Steyaert J, . Executive functioning in autism spectrum disorders: influence of task and sample characteristics and relation to symptom severity. Eur Child Adolesc Psychiatry. 2015 Feb 20 doi: 10.1007/s00787-015-0689-1. X-1
4398 Van Hecke AV, Stevens S, Carson AM, . Measuring the plasticity of social approach: a randomized controlled trial of the effects of the PEERS intervention on EEG asymmetry in adolescents with autism spectrum disorders. J Autism Dev Disord. 2015 Feb;45(2):316–35. doi: 10.1007/s10803-013-1883-y. X-123812665
4399 van Iterson L, de Jong PF, Zijlstra BJ. Pediatric epilepsy and comorbid reading disorders, math disorders, or autism spectrum disorders: Impact of epilepsy on cognitive patterns. Epilepsy Behav. 2015 Mar;44:159–68. doi: 10.1016/j.yebeh.2015.02.007. X-125723912
4400 Van Naarden Braun K, Christensen D, Doernberg N, . Trends in the prevalence of autism spectrum disorder, cerebral palsy, hearing loss, intellectual disability, and vision impairment, metropolitan atlanta, 1991–2010. PLoS One. 2015;10(4):e0124120. doi: 10.1371/journal.pone.0124120. X-125923140
4401 van Rijn S. Social Attention in 47,XXY (Klinefelter Syndrome): Visual Scanning of Facial Expressions Using Eyetracking. J Int Neuropsychol Soc. 2015 May;21(5):364–72. doi: 10.1017/s1355617715000302. X-126018944
4402 van Steensel FJ, Bogels SM. CBT for anxiety disorders in children with and without autism spectrum disorders. J Consult Clin Psychol. 2015 Jun;83(3):512–23. doi: 10.1037/a0039108. X-125894668
4403 van Tongerloo MA, van Wijngaarden PJ, van der Gaag RJ, . Raising a child with an Autism Spectrum Disorder: ‘If this were a partner relationship, I would have quit ages ago’. Fam Pract. 2015 Feb;32(1):88–93. doi: 10.1093/fampra/cmu076. X-125425636
4404 VanDam M, Oller DK, Ambrose SE, . Automated Vocal Analysis of Children With Hearing Loss and Their Typical and Atypical Peers. Ear Hear. 2015 Jul–Aug;36(4):e146–52. doi: 10.1097/aud.0000000000000138. X-125587667
4405 VanderLaan DP, Postema L, Wood H, . Do children with gender dysphoria have intense/obsessional interests? J Sex Res. 2015;52(2):213–9. doi: 10.1080/00224499.2013.860073. X-124558954
4406 Vandermeer J, Beamish W, Milford T, . iPad-presented social stories for young children with autism. Dev Neurorehabil. 2015 Apr;18(2):75–81. doi: 10.3109/17518423.2013.809811. X-3, X-423815083
4407 Vanmarcke S, Van Der Hallen R, Evers K, . Ultra-Rapid Categorization of Meaningful Real-Life Scenes in Adults With and Without ASD. J Autism Dev Disord. 2015 Sep 9 doi: 10.1007/s10803-015-2583-6. X-1
4408 Vasconcellos LF, Pereira JS. Parkinson’s disease dementia: Diagnostic criteria and risk factor review. J Clin Exp Neuropsychol. 2015 Nov;37(9):988–93. doi: 10.1080/13803395.2015.1073227. X-126332178
4409 Veale D, Miles S, Read J, . Penile Dysmorphic Disorder: Development of a Screening Scale. Arch Sex Behav. 2015 Mar 3 doi: 10.1007/s10508-015-0484-6. X-1
4410 Veatch OJ, Goldman SE, Adkins KW, . Melatonin in Children with Autism Spectrum Disorders: How Does the Evidence Fit Together? J Nat Sci. 2015;1(7):e125. X-126120597
4411 Veatch OJ, Maxwell-Horn AC, Malow BA. Sleep in Autism Spectrum Disorders. Curr Sleep Med Rep. 2015 Jun;1(2):131–40. doi: 10.1007/s40675-015-0012-1. X-126046012
4412 Vedora J, Grandelski K. A comparison of methods for teaching receptive language to toddlers with autism. J Appl Behav Anal. 2015 Spring;48(1):188–93. doi: 10.1002/jaba.167. X-1, X-325303362
4413 Ventola P, Yang DY, Friedman HE, . Heterogeneity of neural mechanisms of response to pivotal response treatment. Brain Imaging Behav. 2015 Mar;9(1):74–88. doi: 10.1007/s11682-014-9331-y. X-125370452
4414 Verhoeff B. Two kinds of autism: a comparison of distinct understandings of psychiatric disease. Med Health Care Philos. 2015 Jun 28 doi: 10.1007/s11019-015-9655-4. X-1
4415 Ververi A, Vargiami E, Papadopoulou V, . Brainstem Auditory Evoked Potentials in Boys with Autism: Still Searching for the Hidden Truth. Iran J Child Neurol. 2015 Spring;9(2):21–8. X-126221159
4416 Vesperini S, Askenazy F, Renaudo N, . [Prosocial intervention in children and adolescents with autism spectrum disorder without intellectual disability: benefits of videotaping therapy sessions]. Encephale. 2015 Feb;41(1):47–55. doi: 10.1016/j.encep.2013.04.015. X-3, X-425439857
4417 Viaggi C, Gerace C, Pardini C, . Serotonin abnormalities in Engrailed-2 knockout mice: New insight relevant for a model of Autism Spectrum Disorder. Neurochem Int. 2015 Aug;87:34–42. doi: 10.1016/j.neuint.2015.05.004. X-126002543
4418 Viggiano D, Ianiro G, Vanella G, . Gut barrier in health and disease: focus on childhood. Eur Rev Med Pharmacol Sci. 2015;19(6):1077–85. X-125855935
4419 Vinet E, Pineau CA, Clarke AE, . Increased Risk of Autism Spectrum Disorders in Children Born to Women with Systemic Lupus Erythematosus: Results from the OSLER Cohort. Arthritis Rheumatol. 2015 Aug 28 doi: 10.1002/art.39320. X-1
4420 Virk J, Liew Z, Olsen J, . Preconceptional and prenatal supplementary folic acid and multivitamin intake and autism spectrum disorders. Autism. 2015 Sep 25 doi: 10.1177/1362361315604076. X-1
4421 Visser K, Greaves-Lord K, Tick NT, . Study protocol: a randomized controlled trial investigating the effects of a psychosexual training program for adolescents with autism spectrum disorder. BMC Psychiatry. 2015;15(1):207. doi: 10.1186/s12888-015-0586-7. X-126310577
4422 Vitiello B, Lazzaretto D, Yershova K, . Pharmacotherapy of the Preschool ADHD Treatment Study (PATS) Children Growing Up. J Am Acad Child Adolesc Psychiatry. 2015 Jul;54(7):550–6. doi: 10.1016/j.jaac.2015.04.004. X-126088659
4423 Vogt D, Cho KK, Lee AT, . The parvalbumin/somatostatin ratio is increased in Pten mutant mice and by human PTEN ASD alleles. Cell Rep. 2015 May 12;11(6):944–56. doi: 10.1016/j.celrep.2015.04.019. X-125937288
4424 von Gontard A, Pirrung M, Niemczyk J, . Incontinence in children with autism spectrum disorder. J Pediatr Urol. 2015 Oct;11(5):264.e1–.e7. doi: 10.1016/j.jpurol.2015.04.015. X-126052001
4425 von Stulpnagel C, Funke C, Haberl C, . SYNGAP1 Mutation in Focal and Generalized Epilepsy: A Literature Overview and A Case Report with Special Aspects of the EEG. Neuropediatrics. 2015 Aug;46(4):287–91. doi: 10.1055/s-0035-1554098. X-126110312
4426 Vonck S, Swinnen SP, Wenderoth N, . Effects of Transcranial Direct Current Stimulation on the Recognition of Bodily Emotions from Point-Light Displays. Front Hum Neurosci. 2015;9:438. doi: 10.3389/fnhum.2015.00438. X-126283952
4427 Wachtel L, Commins E, Park M, . Neuroleptic malignant syndrome and delirious mania as malignant catatonia in autism: prompt relief with electroconvulsive therapy. Acta Psychiatr Scand. 2015 Oct;132(4):319–20. doi: 10.1111/acps.12441. X-1, X-226018851
4428 Wainer AL, Ingersoll BR. Increasing Access to an ASD Imitation Intervention Via a Telehealth Parent Training Program. J Autism Dev Disord. 2015 Dec;45(12):3877–90. doi: 10.1007/s10803-014-2186-7. X-2, X-325035089
4429 Wakeford S, Hinvest N, Ring H, . Autistic characteristics in adults with epilepsy and perceived seizure activity. Epilepsy Behav. 2015 Oct 13;52(Pt A):244–50. doi: 10.1016/j.yebeh.2015.08.031. X-126474368
4430 Wallace GL, Eisenberg IW, Robustelli B, . Longitudinal cortical development during adolescence and young adulthood in autism spectrum disorder: increased cortical thinning but comparable surface area changes. J Am Acad Child Adolesc Psychiatry. 2015 Jun;54(6):464–9. doi: 10.1016/j.jaac.2015.03.007. X-126004661
4431 Walsh JA, Vida MD, Morrisey MN, . Adults with autism spectrum disorder show evidence of figural aftereffects with male and female faces. Vision Res. 2015 Oct;115(Pt A):104–12. doi: 10.1016/j.visres.2015.08.010. X-126322382
4432 Walton KM, Ingersoll BR. The influence of maternal language responsiveness on the expressive speech production of children with autism spectrum disorders: a microanalysis of mother-child play interactions. Autism. 2015 May;19(4):421–32. doi: 10.1177/1362361314523144. X-1, X-324566717
4433 Walton KM, Ingersoll BR. Psychosocial Adjustment and Sibling Relationships in Siblings of Children with Autism Spectrum Disorder: Risk and Protective Factors. J Autism Dev Disord. 2015 Sep;45(9):2764–78. doi: 10.1007/s10803-015-2440-7. X-125847756
4434 Waltz MM. Mothers and autism: the evolution of a discourse of blame. AMA J Ethics. 2015 Apr;17(4):353–8. doi: 10.1001/journalofethics.2015.17.4.mhst1-1504. X-125901704
4435 Wang C, Shimojo E, Shimojo S. Don’t look at the eyes: Live interaction reveals strong eye avoidance behavior in autism. J Vis. 2015 Sep 1;15(12):648. doi: 10.1167/15.12.648. X-1
4436 Wang G, Liu Z, Xu G, . Sleep Disturbances and Associated Factors in Chinese Children with Autism Spectrum Disorder: A Retrospective and Cross-Sectional Study. Child Psychiatry Hum Dev. 2015 Jun 14 doi: 10.1007/s10578-015-0561-z. X-1
4437 Wang H, Doering LC. Autism spectrum disorders: emerging mechanisms and mechanism-based treatment. Front Cell Neurosci. 2015;9:183. doi: 10.3389/fncel.2015.00183. X-1, X-2, X-326029053
4438 Wang KS, Tonarelli S, Luo X, . Polymorphisms within ASTN2 gene are associated with age at onset of Alzheimer’s disease. J Neural Transm (Vienna). 2015 May;122(5):701–8. doi: 10.1007/s00702-014-1306-z. X-125410587
4439 Wang L, Almeida LE, Spornick NA, . Modulation of social deficits and repetitive behaviors in a mouse model of autism: the role of the nicotinic cholinergic system. Psychopharmacology (Berl). 2015 Dec;232(23):4303–16. doi: 10.1007/s00213-015-4058-z. X-126337613
4440 Wang M, Chen H, Yu T, . Increased serum levels of brain-derived neurotrophic factor in autism spectrum disorder. Neuroreport. 2015 Aug 5;26(11):638–41. doi: 10.1097/wnr.0000000000000404. X-126103118
4441 Wang T, de Kok L, Willemsen R, . In vivo synaptic transmission and morphology in mouse models of Tuberous sclerosis, Fragile X syndrome, Neurofibromatosis type 1, and Costello syndrome. Front Cell Neurosci. 2015;9:234. doi: 10.3389/fncel.2015.00234. X-126190969
4442 Wang Z, Magnon GC, White SP, . Individuals with autism spectrum disorder show abnormalities during initial and subsequent phases of precision gripping. J Neurophysiol. 2015 Apr 1;113(7):1989–2001. doi: 10.1152/jn.00661.2014. X-125552638
4443 Warfield ME, Crossman MK, Delahaye J, . Physician Perspectives on Providing Primary Medical Care to Adults with Autism Spectrum Disorders (ASD). J Autism Dev Disord. 2015 Jul;45(7):2209–17. doi: 10.1007/s10803-015-2386-9. X-125724445
4444 Warnell F, George B, McConachie H, . Designing and recruiting to UK autism spectrum disorder research databases: do they include representative children with valid ASD diagnoses? BMJ Open. 2015;5(9):e008625. doi: 10.1136/bmjopen-2015-008625. X-1
4445 Warren ZE, Zheng Z, Swanson AR, . Can Robotic Interaction Improve Joint Attention Skills? J Autism Dev Disord. 2015 Nov;45(11):3726–34. doi: 10.1007/s10803-013-1918-4. X-3, X-424014194
4446 Watanabe T, Kuroda M, Kuwabara H, . Clinical and neural effects of six-week administration of oxytocin on core symptoms of autism. Brain. 2015 Sep 3 doi: 10.1093/brain/awv249. X-1
4447 Watling R, Hauer S. Effectiveness of Ayres Sensory Integration((R)) and Sensory-Based Interventions for People With Autism Spectrum Disorder: A Systematic Review. Am J Occup Ther. 2015 Sep–Oct;69(5):6905180030p1–p12. doi: 10.5014/ajot.2015.018051. X-2
4448 Weaver LL. Effectiveness of Work, Activities of Daily Living, Education, and Sleep Interventions for People With Autism Spectrum Disorder: A Systematic Review. Am J Occup Ther. 2015 Sep–Oct;69(5):6905180020p1–p11. doi: 10.5014/ajot.2015.017962. X-1, X-2
4449 Webb S, Bernier R, Henderson H, . Guidelines and Best Practices for Electrophysiological Data Collection, Analysis and Reporting in Autism. Journal of Autism & Developmental Disorders. 2015;45(2):425–43 19p. doi: 10.1007/s10803-013-1916-6. Language: English. Entry Date: 20150203. Revision Date: 20150710. Publication Type: Journal Article. X-123975145
4450 Weber J, Gutierrez A, Jr. A Treatment Package without Escape Extinction to Address Food Selectivity. J Vis Exp. 2015(102):e52898. doi: 10.3791/52898. X-526325108
4451 Weeks S, Atlas A. Clinical audit for occupational therapy intervention for children with autism spectrum disorder: sampling steps and sample size calculation. BMC Res Notes. 2015;8:282. doi: 10.1186/s13104-015-1247-0. X-126122044
4452 Wei D, Lee D, Cox CD, . Endocannabinoid signaling mediates oxytocin-driven social reward. Proc Natl Acad Sci U S A. 2015 Nov 10;112(45):14084–9. doi: 10.1073/pnas.1509795112. X-126504214
4453 Weimer K, Colloca L, Enck P. Placebo effects in psychiatry: mediators and moderators. Lancet Psychiatry. 2015 Mar 1;2(3):246–57. doi: 10.1016/s2215-0366(14)00092-3. X-1, X-225815249
4454 Weir RK, Forghany R, Smith SE, . Preliminary evidence of neuropathology in nonhuman primates prenatally exposed to maternal immune activation. Brain Behav Immun. 2015 Aug;48:139–46. doi: 10.1016/j.bbi.2015.03.009. X-125816799
4455 Weismuller B, Thienel R, Youlden AM, . Psychophysiological Correlates of Developmental Changes in Healthy and Autistic Boys. J Autism Dev Disord. 2015 Jul;45(7):2168–75. doi: 10.1007/s10803-015-2385-x. X-125663626
4456 Weiss JA, Burnham Riosa P. Thriving in Youth with Autism Spectrum Disorder and Intellectual Disability. J Autism Dev Disord. 2015 Aug;45(8):2474–86. doi: 10.1007/s10803-015-2412-y. X-125772536
4457 Weiss JA, Tint A, Paquette-Smith M, . Perceived self-efficacy in parents of adolescents and adults with autism spectrum disorder. Autism. 2015 May 27 doi: 10.1177/1362361315586292. X-1
4458 Welch MG, Firestein MR, Austin J, . Family Nurture Intervention in the Neonatal Intensive Care Unit improves social-relatedness, attention, and neurodevelopment of preterm infants at 18 months in a randomized controlled trial. J Child Psychol Psychiatry. 2015 Nov;56(11):1202–11. doi: 10.1111/jcpp.12405. X-125763525
4459 Werling DM, Geschwind DH. Recurrence rates provide evidence for sex-differential, familial genetic liability for autism spectrum disorders in multiplex families and twins. Mol Autism. 2015;6:27. doi: 10.1186/s13229-015-0004-5. X-125973164
4460 West JD, Cheetham TD, Dane C, . Should radioiodine be the first-line treatment for paediatric Graves’ disease? J Pediatr Endocrinol Metab. 2015 Jul;28(7–8):797–804. doi: 10.1515/jpem-2014-0176. X-125719296
4461 West M, Targett P, Wehman P, . Separation from supported employment: a retrospective chart review study. Disabil Rehabil. 2015;37(12):1055–9. doi: 10.3109/09638288.2014.955133. X-125162839
4462 Weston B, Fogal B, Cook D, . An agent-based modeling framework for evaluating hypotheses on risks for developing autism: effects of the gut microbial environment. Med Hypotheses. 2015 Apr;84(4):395–401. doi: 10.1016/j.mehy.2015.01.027. X-125670416
4463 Whipple CM, Gfeller K, Driscoll V, . Do communication disorders extend to musical messages? An answer from children with hearing loss or autism spectrum disorders. J Music Ther. 2015 Spring;52(1):78–116. doi: 10.1093/jmt/thu039. X-125691513
4464 Whissell PD, Cajanding JD, Fogel N, . Comparative density of CCK- and PV-GABA cells within the cortex and hippocampus. Front Neuroanat. 2015;9:124. doi: 10.3389/fnana.2015.00124. X-126441554
4465 White SW, Maddox BB, Panneton RK. Fear of Negative Evaluation Influences Eye Gaze in Adolescents with Autism Spectrum Disorder: A Pilot Study. J Autism Dev Disord. 2015 Nov;45(11):3446–57. doi: 10.1007/s10803-014-2349-6. X-125578337
4466 White SW, Schry AR, Miyazaki Y, . Effects of Verbal Ability and Severity of Autism on Anxiety in Adolescents With ASD: One-Year Follow-Up After Cognitive Behavioral Therapy. J Clin Child Adolesc Psychol. 2015;44(5):839–45. doi: 10.1080/15374416.2014.893515. X-124731184
4467 Whiteley P. Nutritional management of (some) autism: a case for gluten- and casein-free diets? Proc Nutr Soc. 2015 Aug;74(3):202–7. doi: 10.1017/s0029665114001475. X-225311313
4468 Whitney RV, Smith G. Emotional Disclosure Through Journal Writing: Telehealth Intervention for Maternal Stress and Mother-Child Relationships. J Autism Dev Disord. 2015 Nov;45(11):3735–45. doi: 10.1007/s10803-014-2332-2. X-125503483
4469 Whyte E, Elbich D, Behrmann M, . Altered functional connectivity in the core and extended face-processing network in adolescents with autism. J Vis. 2015 Sep 1;15(12):1209. doi: 10.1167/15.12.1209. X-1
4470 Whyte EM, Nelson KE. Trajectories of pragmatic and nonliteral language development in children with autism spectrum disorders. J Commun Disord. 2015 Mar–Apr;54:2–14. doi: 10.1016/j.jcomdis.2015.01.001. X-125638464
4471 Wiggins LD, Levy SE, Daniels J, . Autism Spectrum Disorder Symptoms Among Children Enrolled in the Study to Explore Early Development (SEED). J Autism Dev Disord. 2015 Oct;45(10):3183–94. doi: 10.1007/s10803-015-2476-8. X-126048040
4472 Wiggins LD, Reynolds A, Rice CE, . Using standardized diagnostic instruments to classify children with autism in the study to explore early development. J Autism Dev Disord. 2015 May;45(5):1271–80. doi: 10.1007/s10803-014-2287-3. X-125348175
4473 Wijma RA, van der Nagel BC, Dierckx B, . Identification and quantification of the antipsychotics risperidone, aripiprazole, pipamperone and their major metabolites in plasma using ultra-high performance liquid chromatography-mass spectrometry. Biomed Chromatogr. 2015 Sep 7 doi: 10.1002/bmc.3610. X-1
4474 Wijnhoven LA, Creemers DH, Engels RC, . The effect of the video game Mindlight on anxiety symptoms in children with an Autism Spectrum Disorder. BMC Psychiatry. 2015;15:138. doi: 10.1186/s12888-015-0522-x. X-1, X-226129831
4475 Wilkes BJ, T BC, Patel KP, . Oculomotor performance in children with high-functioning Autism Spectrum Disorders. Res Dev Disabil. 2015 Mar;38:338–44. doi: 10.1016/j.ridd.2014.12.022. X-125590171
4476 Williamson KE, Jakobson LS, Saunders DR, . Local and global aspects of biological motion perception in children born at very low birth weight. Child Neuropsychol. 2015 Sep;21(5):603–28. doi: 10.1080/09297049.2014.945407. X-125103588
4477 Willing J, Wagner CK. Progesterone Receptor Expression in the Developing Mesocortical Dopamine Pathway: Importance for Complex Cognitive Behavior in Adulthood. Neuroendocrinology. 2015 Jun 10 doi: 10.1159/000434725. X-1
4478 Winarni TI, Schneider A, Ghaziuddin N, . Psychosis and catatonia in fragile X: Case report and literature review. Intractable Rare Dis Res. 2015 Aug;4(3):139–46. doi: 10.5582/irdr.2015.01028. X-126361565
4479 Windham GC, Lyall K, Anderson M, . Autism Spectrum Disorder Risk in Relation to Maternal Mid-Pregnancy Serum Hormone and Protein Markers from Prenatal Screening in California. J Autism Dev Disord. 2015 Sep 14 doi: 10.1007/s10803-015-2587-2. X-1
4480 Wink LK, Fitzpatrick S, Shaffer R, . The neurobehavioral and molecular phenotype of Angelman Syndrome. Am J Med Genet A. 2015 Nov;167(11):2623–8. doi: 10.1002/ajmg.a.37254. X-1
4481 Wink LK, Pedapati EV, Horn PS, . Multiple Antipsychotic Medication Use in Autism Spectrum Disorder. J Child Adolesc Psychopharmacol. 2015 Oct 14 doi: 10.1089/cap.2015.0123. X-1
4482 Wohr M. Effect of social odor context on the emission of isolation-induced ultrasonic vocalizations in the BTBR T+tf/J mouse model for autism. Front Neurosci. 2015;9:73. doi: 10.3389/fnins.2015.00073. X-125852455
4483 Wolfberg P, DeWitt M, Young GS, . Integrated play groups: promoting symbolic play and social engagement with typical peers in children with ASD across settings. J Autism Dev Disord. 2015 Mar;45(3):830–45. doi: 10.1007/s10803-014-2245-0. X-1, X-325231289
4484 Wolfe FH, Auzias G, Deruelle C, . Focal atrophy of the hypothalamus associated with third ventricle enlargement in autism spectrum disorder. Neuroreport. 2015 Oct 6 doi: 10.1097/wnr.0000000000000461. X-1
4485 Wolff AR, Bilkey DK. Prenatal immune activation alters hippocampal place cell firing characteristics in adult animals. Brain Behav Immun. 2015 Aug;48:232–43. doi: 10.1016/j.bbi.2015.03.012. X-125843370
4486 Wong C, Odom SL, Hume KA, . Evidence-Based Practices for Children, Youth, and Young Adults with Autism Spectrum Disorder: A Comprehensive Review. J Autism Dev Disord. 2015 Jul;45(7):1951–66. doi: 10.1007/s10803-014-2351-z. X-225578338
4487 Wong PH, White KM. Impact of Immunoglobulin Therapy in Pediatric Disease: a Review of Immune Mechanisms. Clin Rev Allergy Immunol. 2015 Jul 4 doi: 10.1007/s12016-015-8499-2. X-1, X-2
4488 Wong VC, Fung CW, Kwong AK. SCN2A mutation in a Chinese boy with infantile spasm - response to Modified Atkins Diet. Brain Dev. 2015 Aug;37(7):729–32. doi: 10.1016/j.braindev.2014.10.008. X-125459969
4489 Wong VC, Fung CW, Lee SL, . Review of evolution of clinical, training and educational services and research program for autism spectrum disorders in Hong Kong. Sci China Life Sci. 2015 Oct;58(10):991–1009. doi: 10.1007/s11427-012-4294-y. X-1, X-226335731
4490 Wong VC, Kwong AK. CDKL5 variant in a boy with infantile epileptic encephalopathy: case report. Brain Dev. 2015 Apr;37(4):446–8. doi: 10.1016/j.braindev.2014.07.003. X-125085838
4491 Wood AG, Nadebaum C, Anderson V, . Prospective assessment of autism traits in children exposed to antiepileptic drugs during pregnancy. Epilepsia. 2015 Jul;56(7):1047–55. doi: 10.1111/epi.13007. X-125963613
4492 Wood JJ, Ehrenreich-May J, Alessandri M, . Cognitive behavioral therapy for early adolescents with autism spectrum disorders and clinical anxiety: a randomized, controlled trial. Behav Ther. 2015 Jan;46(1):7–19. doi: 10.1016/j.beth.2014.01.002. X-125526831
4493 Worley G, Crissman BG, Cadogan E, . Down Syndrome Disintegrative Disorder: New-Onset Autistic Regression, Dementia, and Insomnia in Older Children and Adolescents With Down Syndrome. J Child Neurol. 2015 Aug;30(9):1147–52. doi: 10.1177/0883073814554654. X-125367918
4494 Wright HF, Hall S, Hames A, . Acquiring a Pet Dog Significantly Reduces Stress of Primary Carers for Children with Autism Spectrum Disorder: A Prospective Case Control Study. J Autism Dev Disord. 2015 Aug;45(8):2531–40. doi: 10.1007/s10803-015-2418-5. X-125832799
4495 Ws A, Zwaigenbaum L, Nicholas D, . Factors influencing autism spectrum disorder screening by community paediatricians. Paediatr Child Health. 2015 Jun–Jul;20(5):e20–4. X-126175565
4496 Wu J, de Theije CG, da Silva SL, . mTOR plays an important role in cow’s milk allergy-associated behavioral and immunological deficits. Neuropharmacology. 2015 Oct;97:220–32. doi: 10.1016/j.neuropharm.2015.04.035. X-126027949
4497 Wunderlich KL, Vollmer TR. Data analysis of response interruption and redirection as a treatment for vocal stereotypy. J Appl Behav Anal. 2015 Jul 14 doi: 10.1002/jaba.227. X-3, X-4
4498 Wynter K, Hammarberg K, Sartore GM, . Brief online surveys to monitor and evaluate facilitated peer support groups for caregivers of children with special needs. Eval Program Plann. 2015 Apr;49:70–5. doi: 10.1016/j.evalprogplan.2014.12.019. X-125559709
4499 Xiang J, Korostenskaja M, Molloy C, . Multi-frequency localization of aberrant brain activity in autism spectrum disorder. Brain Dev. 2015 Apr 27 doi: 10.1016/j.braindev.2015.04.007. X-1
4500 Xie B, Agam G, Balasubramanian S, . Disease gene prioritization using network and feature. J Comput Biol. 2015 Apr;22(4):313–23. doi: 10.1089/cmb.2015.0001. X-125844670
4501 Xu H, Wang Y, He Z, . Direct conversion of mouse fibroblasts to GABAergic neurons with combined medium without the introduction of transcription factors or miRNAs. Cell Cycle. 2015 Aug 3;14(15):2451–60. doi: 10.1080/15384101.2015.1060382. X-126114472
4502 Xu L, Ma X, Zhao W, . Oxytocin enhances attentional bias for neutral and positive expression faces in individuals with higher autistic traits. Psychoneuroendocrinology. 2015 Sep 5;62:352–8. doi: 10.1016/j.psyneuen.2015.09.002. X-126372768
4503 Yakubova G, Hughes EM, Hornberger E. Video-Based Intervention in Teaching Fraction Problem-Solving to Students with Autism Spectrum Disorder. J Autism Dev Disord. 2015 Sep;45(9):2865–75. doi: 10.1007/s10803-015-2449-y. X-1, X-3, X-425911304
4504 Yan CL, Zhang J, Hou Y. Decreased plasma levels of lipoxin A4 in children with autism spectrum disorders. Neuroreport. 2015 Apr 15;26(6):341–5. doi: 10.1097/wnr.0000000000000350. X-125714424
4505 Yang C, Hao Z, Zhang LL, . Efficacy and safety of acupuncture in children: an overview of systematic reviews. Pediatr Res. 2015 Aug;78(2):112–9. doi: 10.1038/pr.2015.91. X-2, X-325950453
4506 Yang CJ, Liu CL, Sang B, . The combined role of serotonin and interleukin-6 as biomarker for autism. Neuroscience. 2015 Jan 22;284:290–6. doi: 10.1016/j.neuroscience.2014.10.011. X-125453766
4507 Yang H, Lu X, He H, . Longer plate-to-disc distance prevents adjacent-level ossification development but does not influence adjacent-segment degeneration. Spine (Phila Pa 1976). 2015 Apr 1;40(7):E388–93. doi: 10.1097/brs.0000000000000800. X-125627288
4508 Yang J, Hofmann J. Action observation and imitation in autism spectrum disorders: an ALE meta-analysis of fMRI studies. Brain Imaging Behav. 2015 Sep 24 doi: 10.1007/s11682-015-9456-7. X-1
4509 Yang M, Lewis F, Foley G, . In tribute to Bob Blanchard: Divergent behavioral phenotypes of 16p11.2 deletion mice reared in same-genotype versus mixed-genotype cages. Physiol Behav. 2015 Jul 1;146:16–27. doi: 10.1016/j.physbeh.2015.04.023. X-126066718
4510 Yang M, Mahrt EJ, Lewis F, . 16p11.2 Deletion Syndrome Mice Display Sensory and Ultrasonic Vocalization Deficits During Social Interactions. Autism Res. 2015 Oct;8(5):507–21. doi: 10.1002/aur.1465. X-125663600
4511 Yang Z, Matsumoto A, Nakayama K, . Circadian-relevant genes are highly polymorphic in autism spectrum disorder patients. Brain Dev. 2015 May 6 doi: 10.1016/j.braindev.2015.04.006. X-1
4512 Yerys BE, Antezana L, Weinblatt R, . Neural Correlates of Set-Shifting in Children With Autism. Autism Res. 2015 Aug;8(4):386–97. doi: 10.1002/aur.1454. X-125599972
4513 Yeung MK, Han YM, Sze SL, . Abnormal Frontal Theta Oscillations Underlie the Cognitive Flexibility Deficits in Children With High-Functioning Autism Spectrum Disorders. Neuropsychology. 2015 Aug 10 doi: 10.1037/neu0000231. X-1
4514 Yirmiya N, Seidman I, Koren-Karie N, . Stability and change in resolution of diagnosis among parents of children with autism spectrum disorder: Child and parental contributions. Dev Psychopathol. 2015 Nov;27(4 Pt 1):1045–57. doi: 10.1017/s095457941500067x. X-126439061
4515 Yoder P, Watson LR, Lambert W. Value-added predictors of expressive and receptive language growth in initially nonverbal preschoolers with autism spectrum disorders. J Autism Dev Disord. 2015 May;45(5):1254–70. doi: 10.1007/s10803-014-2286-4. X-125344152
4516 Yokoyama S, Al Mahmuda N, Munesue T, . Association Study between the CD157/BST1 Gene and Autism Spectrum Disorders in a Japanese Population. Brain Sci. 2015;5(2):188–200. doi: 10.3390/brainsci5020188. X-126010484
4517 Young AS, Cooke MR, Taiclet LM. Management of patient with acrometageria for routine dental treatment: a case report. Spec Care Dentist. 2015 Aug 11 doi: 10.1111/scd.12127. X-1
4518 Young HE, Falco RA, Hanita M. Randomized, Controlled Trial of a Comprehensive Program for Young Students with Autism Spectrum Disorder. J Autism Dev Disord. 2015 Oct 5 doi: 10.1007/s10803-015-2597-0. X-1
4519 Young LJ, Barrett CE. Neuroscience. Can oxytocin treat autism? Science. 2015 Feb 20;347(6224):825–6. doi: 10.1126/science.aaa8120. X-125700501
4520 Young NJ, Findling RL. An update on pharmacotherapy for autism spectrum disorder in children and adolescents. Current Opinion in Psychiatry. 2015;28(2):91–101 11p. doi: 10.1097/YCO.0000000000000132. Language: English. Entry Date: 20150821. Revision Date: 20150923. Publication Type: Journal Article. X-225602248
4521 Yu L, Fan Y, Deng Z, . Pitch Processing in Tonal-Language-Speaking Children with Autism: An Event-Related Potential Study. J Autism Dev Disord. 2015 Nov;45(11):3656–67. doi: 10.1007/s10803-015-2510-x. X-126111738
4522 Yui K, Sato A, Imataka G. Mitochondrial Dysfunction and Its Relationship with mTOR Signaling and Oxidative Damage in Autism Spectrum Disorders. Mini Rev Med Chem. 2015;15(5):373–89. X-125910652
4523 Zablotsky B, Pringle BA, Colpe LJ, . Service and treatment use among children diagnosed with autism spectrum disorders. J Dev Behav Pediatr. 2015 Feb–Mar;36(2):98–105. doi: 10.1097/dbp.0000000000000127. X-125650952
4524 Zaidel A, Goin-Kochel RP, Angelaki DE. Self-motion perception in autism is compromised by visual noise but integrated optimally across multiple senses. PNAS Proceedings of the National Academy of Sciences of the United States of America. 2015 2016-06-23;112(20):6461–6. doi: 10.1007/s10803-010-1000-4 http://dx.doi.org/10.1073/pnas.1506582112; 2016-20383-002. X-1
4525 Zalaquett DF, Schonstedt MG, Angeli M, . [Basics of early intervention in children with autism spectrum disorders]. Rev Chil Pediatr. 2015 Mar–Apr;86(2):126–31. doi: 10.1016/j.rchipe.2015.04.025. X-1, X-226235694
4526 Zamora I, Williams ME, Higareda M, . Brief Report: Recruitment and Retention of Minority Children for Autism Research. J Autism Dev Disord. 2015 Sep 24 doi: 10.1007/s10803-015-2603-6. X-1
4527 Zapf AC, Glindemann LA, Vogeley K, . Sex differences in mental rotation and how they add to the understanding of autism. PLoS One. 2015;10(4):e0124628. doi: 10.1371/journal.pone.0124628. X-125884501
4528 Zeidler S, Hukema RK, Willemsen R. The quest for targeted therapy in fragile X syndrome. Expert Opin Ther Targets. 2015 Oct;19(10):1277–81. doi: 10.1517/14728222.2015.1079176. X-126294013
4529 Zerbo O, Yoshida C, Gunderson EP, . Interpregnancy Interval and Risk of Autism Spectrum Disorders. Pediatrics. 2015 Oct;136(4):651–7. doi: 10.1542/peds.2015-1099. X-126371204
4530 Zhan Y. Theta frequency prefrontal-hippocampal driving relationship during free exploration in mice. Neuroscience. 2015 Aug 6;300:554–65. doi: 10.1016/j.neuroscience.2015.05.063. X-126037805
4531 Zhang L, Tang J, Dong Y, . Similarities and Differences in Decision-Making Impairments between Autism Spectrum Disorder and Schizophrenia. Front Behav Neurosci. 2015;9:259. doi: 10.3389/fnbeh.2015.00259. X-126441583
4532 Zhang M, Reyhan M, Kim LH. Depth dose perturbation by a hydrogel fiducial marker in a proton beam. J Appl Clin Med Phys. 2015;16(1):5090. doi: 10.1120/jacmp.v16i1.5090. X-125679167
4533 Zhang Y, Yang C, Yuan G, . Sulindac attenuates valproic acid-induced oxidative stress levels in primary cultured cortical neurons and ameliorates repetitive/stereotypic-like movement disorders in Wistar rats prenatally exposed to valproic acid. Int J Mol Med. 2015 Jan;35(1):263–70. doi: 10.3892/ijmm.2014.1996. X-125384498
4534 Zhao G, Gao J, Liang S, . Study of the serum levels of polyunsaturated fatty acids and the expression of related liver metabolic enzymes in a rat valproate-induced autism model. Int J Dev Neurosci. 2015 Aug;44:14–21. doi: 10.1016/j.ijdevneu.2015.04.350. X-125916973
4535 Zhao HX, Yin SS, Fan JG. High plasma neopterin levels in Chinese children with autism spectrum disorders. Int J Dev Neurosci. 2015 Apr;41:92–7. doi: 10.1016/j.ijdevneu.2015.02.002. X-125660944
4536 Zhen B, Blackwell AF, Coulouris G. Using Augmented Reality to Elicit Pretend Play for Children with Autism. IEEE Trans Vis Comput Graph. 2015 May;21(5):598–610. doi: 10.1109/tvcg.2014.2385092. X-1, X-326357207
4537 Zheng Z, Young E, Swanson A, . Robot-mediated Imitation Skill Training for Children with Autism. IEEE Trans Neural Syst Rehabil Eng. 2015 Sep 3 doi: 10.1109/tnsre.2015.2475724. X-1, X-3
4538 Zhu H, Li J, Fan Y, . Atypical prefrontal cortical responses to joint/non-joint attention in children with autism spectrum disorder (ASD): A functional near-infrared spectroscopy study. Biomed Opt Express. 2015 Mar 1;6(3):690–701. doi: 10.1364/boe.6.000690. X-125798296
4539 Zivoder I, Martic-Biocina S, Kosic AV, . Neurofeedback application in the treatment of autistic spectrum disorders (ASD). Psychiatr Danub. 2015 Sep;27 Suppl 1:391–4. X-3, X-4
4540 Zobel-Lachiusa J, Andrianopoulos MV, Mailloux Z, . Sensory Differences and Mealtime Behavior in Children With Autism. Am J Occup Ther. 2015 Sep–Oct;69(5):6905185050p1–8. doi: 10.5014/ajot.2015.016790. X-126379266
4541 Zuckerman KE, Lindly OJ, Sinche BK, . Parent health beliefs, social determinants of health, and child health services utilization among U.S. school-age children with autism. J Dev Behav Pediatr. 2015 Apr;36(3):146–57. doi: 10.1097/dbp.0000000000000136. X-125741947
4542 Zwaigenbaum L, Bauman ML, Choueiri R, . Early Identification and Interventions for Autism Spectrum Disorder: Executive Summary. Pediatrics. 2015 Oct;136 Suppl 1:S1–9. doi: 10.1542/peds.2014-3667B. X-1, X-226430167
4543 Zwaigenbaum L, Bauman ML, Choueiri R, . Early Intervention for Children With Autism Spectrum Disorder Under 3 Years of Age: Recommendations for Practice and Research. Pediatrics. 2015 Oct;136 Suppl 1:S60–81. doi: 10.1542/peds.2014-3667E. X-126430170
4544 Antidepressants in pregnancy and autism. Arch Dis Child. 2016 Mar;101(3):240. doi: 10.1136/archdischild-2016-310462. X-126787608
4545 Neurodevelopmental disorders: Epilepsy and autism spectrum disorders may have a shared aetiology. Nat Rev Neurol. 2016 Jul 1 doi: 10.1038/nrneurol.2016.100. X-1
4546 A Prospective Open-Label Trial of Memantine Hydrochloride for the Treatment of Social Deficits in Intellectually Capable Adults With Autism Spectrum Disorder: Erratum. J Clin Psychopharmacol. 2016 Aug;36(4):339. doi: 10.1097/jcp.0000000000000534. X-127355795
4547 Aabbassi B, Benali A, Asri F. Risperidone-induced priapism in an autistic child: a case report. J Med Case Rep. 2016;10:164. doi: 10.1186/s13256-016-0956-x. X-1, X-3, X-427266696
4548 Abdelkarim A, Levi DS, Tran B, . Fenestrated Transcatheter ASD Closure in Adults with Diastolic Dysfunction and/or Pulmonary Hypertension: Case Series and Review of the Literature. Congenit Heart Dis. 2016 Apr 29 doi: 10.1111/chd.12367. X-1
4549 Aberle B, Jemmali R, Dirks JH. Effect of sample treatment on biomechanical properties of insect cuticle. Arthropod Struct Dev. 2016 Aug 2 doi: 10.1016/j.asd.2016.08.001. X-1
4550 Abrams DA, Chen T, Odriozola P, . Neural circuits underlying mother’s voice perception predict social communication abilities in children. Proc Natl Acad Sci U S A. 2016 May 31;113(22):6295–300. doi: 10.1073/pnas.1602948113. X-127185915
4551 Abu-Akel A, Apperly IA, Wood SJ, . Autism Tendencies and Psychosis Proneness Interactively Modulate Saliency Cost. Schizophr Bull. 2016 May 23 doi: 10.1093/schbul/sbw066. X-1
4552 Abu-Akel AM, Apperly IA, Wood SJ, . Autism and psychosis expressions diametrically modulate the right temporoparietal junction. Soc Neurosci. 2016 Jun 3:1–13. doi: 10.1080/17470919.2016.1190786. X-1
4553 Acaroglu E, Yavuz AC, Guler UO, . A decision analysis to identify the ideal treatment for adult spinal deformity: is surgery better than non-surgical treatment in improving health-related quality of life and decreasing the disease burden? Eur Spine J. 2016 Jan 28 doi: 10.1007/s00586-016-4413-8. X-1
4554 Achuta VS, Grym H, Putkonen N, . Metabotropic glutamate receptor 5 responses dictate differentiation of neural progenitors to NMDA-responsive cells in fragile X syndrome. Dev Neurobiol. 2016 Jul 13 doi: 10.1002/dneu.22419. X-1
4555 Ackerlund Brandt JA, Weinkauf S, Zeug N, . An evaluation of constant time delay and simultaneous prompting procedures in skill acquisition for young children with autism. Education and Training in Autism and Developmental Disabilities. 2016;51(1):55–66. X-1, X-3, X-4
4556 Adams DJ, Susi A, Erdie-Lalena CR, . Otitis media and related complications among children with autism spectrum disorders. Journal of Autism and Developmental Disorders. 2016;46(5):1636–42. doi: http://dx.doi.org/10.1007/s10803-015-2689-x.x-1 26739355
4557 Adams ILJ, Ferguson GD, Lust JM, . Action planning and position sense in children with Developmental Coordination Disorder. Human Movement Science. 2016;46:196–208. doi: http://dx.doi.org/10.1016/j.humov.2016.01.006. X-126796420
4558 Adams ILJ, Steenbergen B, Lust JM, . Motor imagery training for children with developmental coordination disorder—Study protocol for a randomized controlled trial. BMC Neurology. 2016;16 doi: http://dx.doi.org/10.1186/s12883-016-0530-6. X-126831143
4559 Aggarwala V, Voight BF. An expanded sequence context model broadly explains variability in polymorphism levels across the human genome. Nat Genet. 2016 Apr;48(4):349–55. doi: 10.1038/ng.3511. X-126878723
4560 Agius MM, Vance M. A Comparison of PECS and iPad to Teach Requesting to Pre-schoolers with Autistic Spectrum Disorders. Augment Altern Commun. 2016;32(1):58–68. doi: 10.3109/07434618.2015.1108363. X-1, X-3, X-426586580
4561 Aguilar JM, White PJ, Fragale C, . Preference for language of instruction of an English language learner with autism. Developmental Neurorehabilitation. 2016;19(3):207–10. X-1, X-3, X-426114838
4562 Ahlgrim-Delzell L, Browder DM, Wood L, . Systematic instruction of phonics skills using an iPad for students with developmental disabilities who are AAC users. The Journal of Special Education. 2016;50(2):86–97. doi: http://dx.doi.org/10.1177/0022466915622140. X-1, X-4
4563 Ahmad SF, Zoheir KM, Ansari MA, . Dysregulation of Th1, Th2, Th17, and T regulatory cell-related transcription factor signaling in children with autism. Mol Neurobiol. 2016 Jun 25 doi: 10.1007/s12035-016-9977-0. X-1
4564 Ahn S, Kim TG, Kim KS, . Differentiation of human pluripotent stem cells into Medial Ganglionic Eminence vs. Caudal Ganglionic Eminence cells. Methods. 2016 May 15;101:103–12. doi: 10.1016/j.ymeth.2015.09.009. X-126364591
4565 Ainsworth MK, Evmenova AS, Behrmann M, . Teaching phonics to groups of middle school students with autism, intellectual disabilities and complex communication needs. Res Dev Disabil. 2016 Sep;56:165–76. doi: 10.1016/j.ridd.2016.06.001. X-127318612
4566 Akcakaya NH, Tekturk P, Cagatay A, . Atypical enterovirus encephalitis causing behavioral changes and autism-like clinical manifestations: case report. Acta Neurol Belg. 2016 Feb 19 doi: 10.1007/s13760-016-0614-5. X-1
4567 Akers JS, Higbee TS, Pollard JS, . An evaluation of photographic activity schedules to increase independent playground skills in young children with autism. J Appl Behav Anal. 2016 Jun 10 doi: 10.1002/jaba.327. X-1
4568 Akiyama T, Osaka H, Shimbo H, . SSADH deficiency possibly associated with enzyme activity-reducing SNPs. Brain Dev. 2016 Apr 4 doi: 10.1016/j.braindev.2016.03.008. X-1
4569 Akula VS, Durgaprasad R, Velam V, . Right Ventricle before and after Atrial Septal Defect Device Closure. Echocardiography. 2016 Apr 24 doi: 10.1111/echo.13250. X-1
4570 Alba G, Pereda E, Mañas S, . The variability of EEG functional connectivity of young ADHD subjects in different resting states. Clinical Neurophysiology. 2016;127(2):1321–30. doi: http://dx.doi.org/10.1016/j.clinph.2015.09.134. X-126586514
4571 Aldaqre I, Schuwerk T, Daum MM, . Sensitivity to communicative and non-communicative gestures in adolescents and adults with autism spectrum disorder: saccadic and pupillary responses. Exp Brain Res. 2016 Apr 27 doi: 10.1007/s00221-016-4656-y. X-1
4572 Alentado VJ, Lubelski D, Healy AT, . Predisposing Characteristics of Adjacent Segment Disease Following Lumbar Fusion. Spine (Phila Pa 1976). 2016 Feb 6 doi: 10.1097/brs.0000000000001493. X-1
4573 Ali MA, Tazmin T, Latif T, . Incomplete Pentalogy of Cantrell--A Case Report. Mymensingh Med J. 2016 Jan;25(1):153–7. X-126931266
4574 Aliaga SM, Slater HR, Francis D, . Identification of Males with Cryptic Fragile X Alleles by Methylation-Specific Quantitative Melt Analysis. Clin Chem. 2016 Feb;62(2):343–52. doi: 10.1373/clinchem.2015.244681. X-126715660
4575 Allard MJ, Bergeron JD, Baharnoori M, . A sexually dichotomous, autistic-like phenotype is induced by Group B Streptococcus maternofetal immune activation. Autism Res. 2016 May 25 doi: 10.1002/aur.1647. X-1
4576 Allely CS, Wilson P, Minnis H, . Violence is Rare in Autism: When It Does Occur, Is It Sometimes Extreme? J Psychol. 2016 May 16:1–20. doi: 10.1080/00223980.2016.1175998. X-1
4577 Allen JL, Morris A, Chhoa CY. Callous–unemotional (CU) traits in adolescent boys and response to teacher reward and discipline strategies. Emotional & Behavioural Difficulties. 2016;21(3):329–42. doi: http://dx.doi.org/10.1080/13632752.2016.1165968. X-1
4578 Allen ML, Craig E. Brief report: Imaginative drawing in children with autism spectrum disorder and learning disabilities. Journal of Autism and Developmental Disorders. 2016;46(2):704–12. doi: http://dx.doi.org/10.1007/s10803-015-2599-y. X-126404702
4579 Allin MP. Novel insights from quantitative imaging of the developing cerebellum. Semin Fetal Neonatal Med. 2016 Jun 26 doi: 10.1016/j.siny.2016.06.003. X-1
4580 Allman MJ, Mareschal D. Possible evolutionary and developmental mechanisms of mental time travel (and implications for autism). Curr Opin Behav Sci. 2016 Apr;8:220–5. doi: 10.1016/j.cobeha.2016.02.018. X-127019863
4581 Al-Mendalawi MD. Prevalence of autism spectrum disorders among children (1–10 years of age): Findings of a midterm report from Northwest India. J Postgrad Med. 2016 Jan–Mar;62(1):52–3. doi: 10.4103/0022-3859.173219. X-1
4582 Almirall D, DiStefano C, Chang YC, . Longitudinal Effects of Adaptive Interventions With a Speech-Generating Device in Minimally Verbal Children With ASD. J Clin Child Adolesc Psychol. 2016 Jul–Aug;45(4):442–56. doi: 10.1080/15374416.2016.1138407. X-126954267
4583 Alrayes N, Mohamoud HSA, Ahmed S, . The alkylglycerol monooxygenase (AGMO) gene previously involved in autism also causes a novel syndromic form of primary microcephaly in a consanguineous Saudi family. Journal of the Neurological Sciences. 2016;363:240–4. doi: http://dx.doi.org/10.1016/j.jns.2016.02.063. X-127000257
4584 Alsop B, Furukawa E, Sowerby P, . Behavioral sensitivity to changing reinforcement contingencies in attention-deficit hyperactivity disorder. Journal of Child Psychology and Psychiatry. 2016;57(8):947–56. doi: http://dx.doi.org/10.1111/jcpp.12561. X-127079299
4585 Althaus M, Groen Y, A AW, . Do blood plasma levels of oxytocin moderate the effect of nasally administered oxytocin on social orienting in high-functioning male adults with autism spectrum disorder? Psychopharmacology (Berl). 2016 Jul;233(14):2737–51. doi: 10.1007/s00213-016-4339-1. X-127256356
4586 Altieri N, Yang CT. Parallel linear dynamic models can mimic the McGurk effect in clinical populations. J Comput Neurosci. 2016 Jun 7 doi: 10.1007/s10827-016-0610-z. X-1
4587 Alvares GA, Balleine BW, Whittle L, . Reduced goal-directed action control in autism spectrum disorder. Autism Res. 2016 Mar 21 doi: 10.1002/aur.1613. X-1
4588 Alvarez-Mora MI, Calvo Escalona R, Puig Navarro O, . Comprehensive molecular testing in patients with high functioning autism spectrum disorder. Mutat Res. 2016 Feb–Mar;784–785:46–52. doi: 10.1016/j.mrfmmm.2015.12.006. X-1
4589 Alwan S, Friedman JM, Chambers C. Safety of Selective Serotonin Reuptake Inhibitors in Pregnancy: A Review of Current Evidence. CNS Drugs. 2016 Jun;30(6):499–515. doi: 10.1007/s40263-016-0338-3. X-127138915
4590 Aman MG, Findling RL, Hardan AY, . Safety and Efficacy of Memantine in Children with Autism: Randomized, Placebo-Controlled Study and Open-Label Extension. J Child Adolesc Psychopharmacol. 2016 Mar 15 doi: 10.1089/cap.2015.0146.
4591 Amaral F, Balthazar Jacob MF, Manso PH, . Desmoid Tumor After a Minimally Invasive Atrial Septal Defect Closure in an Adolescent. World J Pediatr Congenit Heart Surg. 2016 Feb 16 doi: 10.1177/2150135115607190. X-1
4592 Ameis SH, Lerch JP, Taylor MJ, . A Diffusion Tensor Imaging Study in Children With ADHD, Autism Spectrum Disorder, OCD, and Matched Controls: Distinct and Non-Distinct White Matter Disruption and Dimensional Brain-Behavior Relationships. Am J Psychiatry. 2016 Jul 1:appiajp201615111435. doi: 10.1176/appi.ajp.2016.15111435. X-1
4593 Amodeo DA, Rivera E, Dunn JT, . M100907 attenuates elevated grooming behavior in the BTBR mouse. Behav Brain Res. 2016 Jul 1;313:67–70. doi: 10.1016/j.bbr.2016.06.064. X-127378338
4594 Amos LE, Carpenter SL, Hoeltzel MF. Lost at Sea in Search of a Diagnosis: A Case of Unexplained Bleeding. Pediatr Blood Cancer. 2016 Jul;63(7):1305–6. doi: 10.1002/pbc.25980. X-127062477
4595 Amram N, Hacohen-Kleiman G, Sragovich S, . Sexual divergence in microtubule function: the novel intranasal microtubule targeting SKIP normalizes axonal transport and enhances memory. Mol Psychiatry. 2016 Jan 19 doi: 10.1038/mp.2015.208. X-1
4596 An JY, Claudianos C. Genetic heterogeneity in autism: From single gene to a pathway perspective. Neurosci Biobehav Rev. 2016 Jun 16;68:442–53. doi: 10.1016/j.neubiorev.2016.06.013. X-127317861
4597 Anagnostou E, Aman MG, Handen BL, . Metformin for Treatment of Overweight Induced by Atypical Antipsychotic Medication in Young People With Autism Spectrum Disorder: A Randomized Clinical Trial. JAMA Psychiatry. 2016 Aug 24 doi: 10.1001/jamapsychiatry.2016.1232. X-1
4598 Andakyan L, Fryling MJ, Benjamin K. Further evaluation of the displacement of leisure items by food during stimulus preference assessments with children with autism. Journal of Developmental and Physical Disabilities. 2016;28(3):461–7. doi: http://dx.doi.org/10.1007/s10882-016-9483-3. X-1, X-3, X-4
4599 Anderson A, Locke J, Kretzmann M, . Social network analysis of children with autism spectrum disorder: Predictors of fragmentation and connectivity in elementary school classrooms. Autism. 2016 Aug;20(6):700–9. doi: 10.1177/1362361315603568. X-126567264
4600 Anderson S, Bucholz JL, Hazelkorn M, . Using narrated literacy-based behavioural interventions to decrease episodes of physical aggression in elementary students with disabilities. Support for Learning. 2016;31(2):90–103. doi: http://dx.doi.org/10.1111/1467-9604.12118. X-1, X-3, X-4
4601 Anderson S, Meints K. Brief Report: The Effects of Equine-Assisted Activities on the Social Functioning in Children and Adolescents with Autism Spectrum Disorder. J Autism Dev Disord. 2016 Jul 25 doi: 10.1007/s10803-016-2869-3. X-3
4602 Anderst W. Narrative review of the in vivo mechanics of the cervical spine after anterior arthrodesis as revealed by dynamic biplane radiography. J Orthop Res. 2016 Jan;34(1):22–30. doi: 10.1002/jor.23042. X-126331480
4603 Andrade NS, Dutra TT, Fernandes RF, . Retrospective study of dental trauma in children with autism spectrum disorders: a paired study. Spec Care Dentist. 2016 Apr 26 doi: 10.1111/scd.12180. X-1
4604 Angioni L, Cocco C, Ferri GL, . Involvement of nigral oxytocin in locomotor activity: A behavioral, immunohistochemical and lesion study in male rats. Horm Behav. 2016 Jul;83:23–38. doi: 10.1016/j.yhbeh.2016.05.012. X-127189764
4605 Annavarapu RN, Kathi S. Cognitive disorders in children associated with urban vehicular emissions. Environ Pollut. 2016 Jan;208(Pt A):74–8. doi: 10.1016/j.envpol.2015.09.036. X-126476694
4606 Antezana L, Mosner MG, Troiani V, . Social-emotional inhibition of return in children with autism spectrum disorder versus typical development. Journal of Autism and Developmental Disorders. 2016;46(4):1236–46. doi: http://dx.doi.org/10.1007/s10803-015-2661-9. X-126586556
4607 Anzures G, Goyet L, Ganea N, . Enhanced ERPs to visual stimuli in unaffected male siblings of ASD children. Child Neuropsychol. 2016;22(2):220–37. doi: 10.1080/09297049.2014.988609. X-125506753
4608 Aponte CA, Romanczyk RG. Assessment of feeding problems in children with autism spectrum disorder. Research in Autism Spectrum Disorders. 2016;21:61–72. doi: http://dx.doi.org/10.1016/j.rasd.2015.09.007. X-1
4609 Arbabshirani MR, Plis S, Sui J, . Single subject prediction of brain disorders in neuroimaging: Promises and pitfalls. Neuroimage. 2016 Mar 21 doi: 10.1016/j.neuroimage.2016.02.079. X-1
4610 Arbogast T, Ouagazzal AM, Chevalier C, . Reciprocal Effects on Neurocognitive and Metabolic Phenotypes in Mouse Models of 16p11.2 Deletion and Duplication Syndromes. PLoS Genet. 2016 Feb;12(2):e1005709. doi: 10.1371/journal.pgen.1005709. X-126872257
4611 Archer T, Kostrzewa RM. Neuroteratology and Animal Modeling of Brain Disorders. Curr Top Behav Neurosci. 2016 Feb 9 doi: 10.1007/7854_2015_434. X-1
4612 Arevalo C, DelRosso LM, Khaytin I, . A 7-Year-Old Boy with Intractable Seizures and Snoring. J Clin Sleep Med. 2016 Feb 29. X-1
4613 Arias VB, Ponce FP, Martínez-Molina A, . General and specific attention-deficit/hyperactivity disorder factors of children 4 to 6 years of age: An exploratory structural equation modeling approach to assessing symptom multidimensionality. Journal of Abnormal Psychology. 2016;125(1):125–37. doi: http://dx.doi.org/10.1037/abn0000115. X-126726819
4614 Arildskov TW, Hojgaard DR, Skarphedinsson G, . Subclinical autism spectrum symptoms in pediatric obsessive-compulsive disorder. Eur Child Adolesc Psychiatry. 2016 Jul;25(7):711–23. doi: 10.1007/s00787-015-0782-5. X-126518580
4615 Arildskov TW, Højgaard DRMA, Skarphedinsson G, . Subclinical autism spectrum symptoms in pediatric obsessive–compulsive disorder. European Child & Adolescent Psychiatry. 2016;25(7):711–23. doi: http://dx.doi.org/10.1007/s00787-015-0782-5. X-126518580
4616 Arima H, Yamato Y, Hasegawa T, . Discrepancy between Standing Posture and Sagittal Balance during Walking in Adult Spinal Deformity Patients. Spine (Phila Pa 1976). 2016 May 23 doi: 10.1097/brs.0000000000001709. X-1
4617 Arkilo D, Devinsky O, Mudigoudar B, . Electroencephalographic patterns during sleep in children with chromosome 15q11.2–13.1 duplications (Dup15q). Epilepsy & Behavior. 2016;57(Part A):133–6. doi: http://dx.doi.org/10.1016/j.yebeh.2016.02.010. X-126949155
4618 Arnevik EA, Helverschou SB. Autism Spectrum Disorder and Co-occurring Substance Use Disorder - A Systematic Review. Subst Abuse. 2016;10:69–75. doi: 10.4137/sart.s39921. X-1, X-227559296
4619 Ashburner J, Vickerstaff S, Beetge J, . Remote versus face-to-face delivery of early intervention programs for children with autism spectrum disorders: Perceptions of rural families and service providers. Research in Autism Spectrum Disorders. 2016;23:1–14. doi: http://dx.doi.org/10.1016/j.rasd.2015.11.011. X-1
4620 Ashwood KL, Gillan N, Horder J, . Predicting the diagnosis of autism in adults using the Autism-Spectrum Quotient (AQ) questionnaire. Psychol Med. 2016 Jun 29:1–10. doi: 10.1017/s0033291716001082. X-1
4621 Ausderau KK, Sideris J, Little LM, . Sensory subtypes and associated outcomes in children with autism spectrum disorders. Autism Res. 2016 May 2 doi: 10.1002/aur.1626. X-1
4622 Austin JE, Zinke VL, Davies WH. Influencing Perception About Children with Autism and their Parents Using Disclosure Cards. J Autism Dev Disord. 2016 May 30 doi: 10.1007/s10803-016-2821-6. X-1
4623 Avella-Garcia CB, Julvez J, Fortuny J, . Acetaminophen use in pregnancy and neurodevelopment: attention function and autism spectrum symptoms. Int J Epidemiol. 2016 Jun 28 doi: 10.1093/ije/dyw115. X-1
4624 Avrech Bar M, Shelef L, Bart O. Do participation and self-efficacy of mothers to children with ASD predict their children’s participation? Research in Autism Spectrum Disorders. 2016;24:1–10. doi: http://dx.doi.org/10.1016/j.rasd.2016.01.002. X-1
4625 Azad GF, Locke J, Kasari C, . Race, disability, and grade: Social relationships in children with autism spectrum disorders. Autism. 2016 Mar 10 doi: 10.1177/1362361315627792. X-1
4626 Azmitia EC, Saccomano ZT, Alzoobaee MF, . Persistent angiogenesis in the autism brain: An immunocytochemical study of postmortem cortex, brainstem and cerebellum. Journal of Autism and Developmental Disorders. 2016;46(4):1307–18. doi: http://dx.doi.org/10.1007/s10803-015-2672-6. X-126667147
4627 Baarsma ME, Boonmann C, t Hart-Kerkhoffs LA, . Sexuality and Autistic-Like Symptoms in Juvenile Sex Offenders: A Follow-Up After 8 Years. J Autism Dev Disord. 2016 May 18 doi: 10.1007/s10803-016-2805-6. X-1
4628 Badone E, Nicholas D, Roberts W, . Asperger’s Syndrome, Subjectivity and the Senses. Cult Med Psychiatry. 2016 Feb 2 doi: 10.1007/s11013-016-9484-9. X-1, X-2, X-3
4629 Baez S, Garcia AM, Ibanez A. The Social Context Network Model in Psychiatric and Neurological Diseases. Curr Top Behav Neurosci. 2016 Apr 30 doi: 10.1007/7854_2016_443. X-1
4630 Baghel S, Cathcart H, O’Reilly NJ. Theoretical and experimental investigation of drug-polymer interaction and miscibility and its impact on drug supersaturation in aqueous medium. Eur J Pharm Biopharm. 2016 Jul 1 doi: 10.1016/j.ejpb.2016.06.024. X-1
4631 Bahi A. Sustained lentiviral-mediated overexpression of microRNA124a in the dentate gyrus exacerbates anxiety- and autism-like behaviors associated with neonatal isolation in rats. Behav Brain Res. 2016 Sep 15;311:298–308. doi: 10.1016/j.bbr.2016.05.033. X-127211062
4632 Bahrami F, Movahedi A, Marandi SM, . The effect of Karate techniques training on communication deficit of children with autism spectrum disorders. Journal of Autism and Developmental Disorders. 2016;46(3):978–86. doi: http://dx.doi.org/10.1007/s10803-015-2643-y. X-126577688
4633 Bai JY, Cowie S, Podlesnik CA. Quantitative analysis of local-level resurgence. Learn Behav. 2016 Aug 5 doi: 10.3758/s13420-016-0242-1. X-1
4634 Baijot S, Slama H, Söderlund G, . Neuropsychological and neurophysiological benefits from white noise in children with and without ADHD. Behavioral and Brain Functions. 2016;12 doi: http://dx.doi.org/10.1186/s12993-016-0095-y. X-127048243
4635 Bakroon A, Lakshminarayanan V. Visual function in autism spectrum disorders: a critical review. Clin Exp Optom. 2016 May 10 doi: 10.1111/cxo.12383. X-1
4636 Bala KA, Dogan M, Mutluer T, . Plasma amino acid profile in autism spectrum disorder (ASD). Eur Rev Med Pharmacol Sci. 2016 Mar;20(5):923–9. X-127010152
4637 Baldwin PR, Curtis KN, Patriquin MA, . Identifying diagnostically-relevant resting state brain functional connectivity in the ventral posterior complex via genetic data mining in autism spectrum disorder. Autism Research. 2016;9(5):553–62. doi: http://dx.doi.org/10.1002/aur.1559. X-126451751
4638 Ballantyne CJ, Núñez M. Developmental trajectories of hierarchical visuo-spatial processing in fragile X syndrome and ASD: Within- and cross-syndrome variability. Research in Developmental Disabilities. 2016;51–52:103–15. doi: http://dx.doi.org/10.1016/j.ridd.2015.12.016. X-1
4639 Ballard J, Crane DR, Harper JM, . Mental health service utilization in autism spectrum disorders. Research in Autism Spectrum Disorders. 2016;23:84–93. doi: http://dx.doi.org/10.1016/j.rasd.2015.12.002. X-1
4640 Balz J, Keil J, Roa Romero Y, . GABA concentration in superior temporal sulcus predicts gamma power and perception in the sound-induced flash illusion. Neuroimage. 2016 Jan 15;125:724–30. doi: 10.1016/j.neuroimage.2015.10.087. X-126546865
4641 Bancroft SL, Thompson RH, Peters LC, . Behavioral variability in the play of children with autism and their typically developing peers. Behavioral Interventions. 2016;31(2):107–19. doi: http://dx.doi.org/10.1002/bin.1438. X-1
4642 Banerjee A, Luong JA, Ho A, . Overexpression of Homer1a in the basal and lateral amygdala impairs fear conditioning and induces an autism-like social impairment. Mol Autism. 2016;7:16. doi: 10.1186/s13229-016-0077-9. X-126929812
4643 Barbaresi WJ. The meaning of “regression” in children with autism spectrum disorder: Why does it matter? Journal of Developmental and Behavioral Pediatrics. 2016;37(6):506–7. doi: http://dx.doi.org/10.1097/DBP.0000000000000325. X-1, X-227366957
4644 Barbaro J, Dissanayake C. Diagnostic stability of autism spectrum disorder in toddlers prospectively identified in a community-based setting: Behavioural characteristics and predictors of change over time. Autism. 2016 Jul 28 doi: 10.1177/1362361316654084. X-1
4645 Barber AB, Saffo RW, Gilpin AT, . Peers as clinicians: Examining the impact of Stay Play Talk on social communication in young preschoolers with autism. Journal of Communication Disorders. 2016;59:1–15. doi: http://dx.doi.org/10.1016/j.jcomdis.2015.06.009. X-3, X-426606507
4646 Bariselli S, Tzanoulinou S, Glangetas C, . SHANK3 controls maturation of social reward circuits in the VTA. Nat Neurosci. 2016 Jul;19(7):926–34. doi: 10.1038/nn.4319. X-127273769
4647 Barker-Haliski ML, Vanegas F, Mau MJ, . Acute cognitive impact of antiseizure drugs in naive rodents and corneal-kindled mice. Epilepsia. 2016 Jul 28 doi: 10.1111/epi.13476. X-1
4648 Barnard-Brak L, Stevens T, Xiao F, . Approaches to learning and medicated ADHD: The potential impact on learning and assessment. Learning and Individual Differences. 2016;47:298–303. doi: http://dx.doi.org/10.1016/j.lindif.2015.12.029. X-1
4649 Barnett R. Attention deficit hyperactivity disorder. The Lancet. 2016;387(10020):737. doi: http://dx.doi.org/10.1016/S0140-6736(16)00332-9. X-1
4650 Barnevik Olsson M, Lundstrom S, Westerlund J, . Preschool to School in Autism: Neuropsychiatric Problems 8 Years After Diagnosis at 3 Years of Age. J Autism Dev Disord. 2016 May 26 doi: 10.1007/s10803-016-2819-0. X-1
4651 Baroncelli L, Molinaro A, Cacciante F, . A mouse model for creatine transporter deficiency reveals early onset cognitive impairment and neuropathology associated with brain aging. Hum Mol Genet. 2016 Jul 27 doi: 10.1093/hmg/ddw252. X-1
4652 Barone R, Sturiale L, Fiumara A, . Csf n-glycan profile reveals sialylation deficiency in a patient with gm2 gangliosidosis presenting as childhood disintegrative disorder. Autism Research. 2016;9(4):423–8. doi: http://dx.doi.org/10.1002/aur.1541. X-126286102
4653 Bartolo A, Ham HS. A Cognitive Overview of Limb Apraxia. Curr Neurol Neurosci Rep. 2016 Aug;16(8):75. doi: 10.1007/s11910-016-0675-0. X-127349561
4654 Bartolome-Villar B, Mourelle-Martinez MR, Dieguez-Perez M, . Incidence of oral health in paediatric patients with disabilities: Sensory disorders and autism spectrum disorder. Systematic review II. J Clin Exp Dent. 2016 Jul;8(3):e344–51. doi: 10.4317/jced.52923. X-127398188
4655 Barton EE, Harris B, Leech N, . An analysis of state autism educational assessment practices and requirements. Journal of Autism and Developmental Disorders. 2016;46(3):737–48. doi: http://dx.doi.org/10.1007/s10803-015-2589-0. X-126363913
4656 Basay BK, Buber A, Basay O, . White matter alterations related to attention-deficit hyperactivity disorder and COMT val^158^met polymorphism: Children with valine homozygote attention-deficit hyperactivity disorder have altered white matter connectivity in the right cingulum (cingulate gyrus). Neuropsychiatric Disease and Treatment. 2016;12. X-1
4657 Baugh EH, Simmons-Edler R, Muller CL, . Robust classification of protein variation using structural modelling and large-scale data integration. Nucleic Acids Res. 2016 Apr 7;44(6):2501–13. doi: 10.1093/nar/gkw120. X-126926108
4658 Bayram AK, Kardas F, Demirci EO, . Lack of serum antineuronal antibodies in children with autism. Bratisl Lek Listy. 2016;117(2):77–9. X-126830036
4659 Beal SJ, Riddle IK, Kichler JC, . The Associations of Chronic Condition Type and Individual Characteristics with Transition Readiness. Acad Pediatr. 2016 Jun 23 doi: 10.1016/j.acap.2016.06.007. X-1
4660 Becker MM, Riesgo RS, Roesler R, . Improvement in Symptoms of Autism Spectrum Disorder in Children With the Use of Gastrin-Releasing Peptide: An Open Trial. Clin Neuropharmacol. 2016 Jun 21 doi: 10.1097/wnf.0000000000000165. X-3
4661 Becker SP, Leopold DR, Burns GL, . The internal, external, and diagnostic validity of sluggish cognitive tempo: A meta-analysis and critical review. Journal of the American Academy of Child & Adolescent Psychiatry. 2016;55(3):163–78. doi: http://dx.doi.org/10.1016/j.jaac.2015.12.006. X-126903250
4662 Becker SP, Withrow AR, Stoppelbein L, . Sluggish cognitive tempo is associated with suicide risk in psychiatrically hospitalized children. J Child Psychol Psychiatry. 2016 Jun 1 doi: 10.1111/jcpp.12580. X-1
4663 Beckman L, Janson S, von Kobyletzki L. Associations between neurodevelopmental disorders and factors related to school, health, and social interaction in schoolchildren: Results from a Swedish population-based survey. Disabil Health J. 2016 May 18 doi: 10.1016/j.dhjo.2016.05.002. X-1
4664 Bedard P. Prenatal Antidepressant Use and Risk of Autism Spectrum Disorders in Children. JAMA Pediatr. 2016 May 31 doi: 10.1001/jamapediatrics.2016.0730. X-1
4665 Bedford R, Pellicano E, Mareschal D, . Flexible integration of visual cues in adolescents with autism spectrum disorder. Autism Res. 2016 Feb;9(2):272–81. doi: 10.1002/aur.1509. X-126097109
4666 Begeer S, Bernstein DM, Aßfalg A, . Reprint of: Equal egocentric bias in school-aged children with and without autism spectrum disorders. Journal of Experimental Child Psychology. 2016;149:134–45. doi: http://dx.doi.org/10.1016/j.jecp.2016.05.017. X-127262614
4667 Begeer S, Bernstein DM, Aßfalg A, . Equal egocentric bias in school-aged children with and without autism spectrum disorders. Journal of Experimental Child Psychology. 2016;144:15–26. doi: http://dx.doi.org/10.1016/j.jecp.2015.10.018. X-126687336
4668 Bekes V, Perry JC, Robertson BM. Psychological masochism: A systematic review of the literature on conflicts, defenses, and motives. Psychother Res. 2016 Jun 1:1–14. doi: 10.1080/10503307.2016.1189618. X-1
4669 Bekhet AK, Matel-Anderson D. Risk and Protective Factors in the Lives of Caregivers of Persons With Autism: Caregivers’ Perspectives. Perspect Psychiatr Care. 2016 Jun 16 doi: 10.1111/ppc.12158. X-1
4670 Belagodu AP, Zendeli L, Slater BJ, . Blocking elevated VEGF-A attenuates non-vasculature Fragile X Syndrome abnormalities. Dev Neurobiol. 2016 Jun 6 doi: 10.1002/dneu.22404. X-1
4671 Belinson H, Nakatani J, Babineau BA, . Prenatal beta-catenin/Brn2/Tbr2 transcriptional cascade regulates adult social and stereotypic behaviors. Mol Psychiatry. 2016 Feb 2 doi: 10.1038/mp.2015.207. X-1
4672 Belisle J, Dixon MR, Stanley CR, . Teaching foundational perspective-taking skills to children with autism using the PEAK-T curriculum: single-reversal “I-You” deictic frames. J Appl Behav Anal. 2016 Jun 9 doi: 10.1002/jaba.324. X-1, X-3
4673 Beltrao-Braga PC, Muotri AR. Modeling autism spectrum disorders with human neurons. Brain Res. 2016 Feb 5 doi: 10.1016/j.brainres.2016.01.057. X-1
4674 Benedek-Wood E, McNaughton D, Light J. Instruction in letter-sound correspondences for children with autism and limited speech. Topics in Early Childhood Special Education. 2016;36(1):43–54. doi: http://dx.doi.org/10.1177/0271121415593497. X-1, X-3, X-4
4675 Ben-Itzchak E, Abutbul S, Bela H, . Understanding one’s own emotions in cognitively-able preadolescents with autism spectrum disorder. Journal of Autism and Developmental Disorders. 2016;46(7):2363–71. doi: http://dx.doi.org/10.1007/s10803-016-2769-6. X-126995198
4676 Ben-Itzchak E, Zukerman G, Zachor DA. Having Older Siblings is Associated with Less Severe Social Communication Symptoms in Young Children with Autism Spectrum Disorder. J Abnorm Child Psychol. 2016 Feb 3 doi: 10.1007/s10802-016-0133-0. X-1
4677 Bennett M, Goodall E. Towards an Agenda for Research for Lesbian, Gay, Bisexual, Transgendered and/or Intersexed People with an Autism Spectrum Diagnosis. J Autism Dev Disord. 2016 Jun 20 doi: 10.1007/s10803-016-2844-z. X-1
4678 Bennett M, Hodgson V. The missing voices of Indigenous Australians with autism in research. Autism. 2016 May 25 doi: 10.1177/1362361316643696. X-1
4679 Benning SD, Kovac M, Campbell A, . Late Positive Potential ERP Responses to Social and Nonsocial Stimuli in Youth with Autism Spectrum Disorder. J Autism Dev Disord. 2016 Jun 25 doi: 10.1007/s10803-016-2845-y. X-1, X-3
4680 Benson PR. The longitudinal effects of network characteristics on the mental health of mothers of children with ASD: The mediating role of parent cognitions. Journal of Autism and Developmental Disorders. 2016;46(5):1699–715. doi: http://dx.doi.org/10.1007/s10803-016-2699-3. X-126810434
4681 Berard A, Boukhris T. Prenatal Antidepressant Use and Risk of Autism Spectrum Disorders in Children-Reply. JAMA Pediatr. 2016 May 31 doi: 10.1001/jamapediatrics.2016.0748. X-1
4682 Berg KL, Shiu CS, Acharya K, . Disparities in adversity among children with autism spectrum disorder: a population-based study. Dev Med Child Neurol. 2016 Jun 2 doi: 10.1111/dmcn.13161. X-1
4683 Berger J, Dorninger F, Forss-Petter S, . Peroxisomes in brain development and function. Biochim Biophys Acta. 2016 May;1863(5):934–55. doi: 10.1016/j.bbamcr.2015.12.005. X-126686055
4684 Berger NI, Manston L, Ingersoll B. Establishing a Scale for Assessing the Social Validity of Skill Building Interventions for Young Children with Autism Spectrum Disorder. J Autism Dev Disord. 2016 Jul 27 doi: 10.1007/s10803-016-2863-9. X-1
4685 Berglund IG, Huus K, Enskär K, . Perioperative and anesthesia guidelines for children with autism: A nationwide survey from Sweden. Journal of Developmental and Behavioral Pediatrics. 2016;37(6):457–64. doi: http://dx.doi.org/10.1097/DBP.0000000000000289. X-127011004
4686 Bergstrom R, Najdowski AC, Alvarado M, . Teaching children with autism to tell socially appropriate lies. J Appl Behav Anal. 2016 Jun;49(2):405–10. doi: 10.1002/jaba.295. X-1, X-326831011
4687 Bergwerff CE, Luman M, Blom HJ, . No Tryptophan, Tyrosine and Phenylalanine Abnormalities in Children with Attention-Deficit/Hyperactivity Disorder. PLoS One. 2016;11(3):e0151100. doi: 10.1371/journal.pone.0151100. X-126938936
4688 Berna F, Goritz AS, Schroder J, . Self-Disorders in Individuals with Autistic Traits: Contribution of Reduced Autobiographical Reasoning Capacities. J Autism Dev Disord. 2016 Apr 21 doi: 10.1007/s10803-016-2797-2. X-1
4689 Bernhardt BC, Di Martino A, Valk SL, . Neuroimaging-Based Phenotyping of the Autism Spectrum. Curr Top Behav Neurosci. 2016 Mar 6 doi: 10.1007/7854_2016_438. X-1
4690 Berryessa CM. Brief Report: Judicial Attitudes Regarding the Sentencing of Offenders with High Functioning Autism. J Autism Dev Disord. 2016 Apr 22 doi: 10.1007/s10803-016-2798-1. X-1
4691 Berry-Kravis E, Des Portes V, Hagerman R, . Mavoglurant in fragile X syndrome: Results of two randomized, double-blind, placebo-controlled trials. Sci Transl Med. 2016 Jan 13;8(321):321ra5. doi: 10.1126/scitranslmed.aab4109. X-1
4692 Berto S, Usui N, Konopka G, . ELAVL2-regulated transcriptional and splicing networks in human neurons link neurodevelopment and autism. Hum Mol Genet. 2016 Jun 3 doi: 10.1093/hmg/ddw110. X-1
4693 Bertorelli TE. Hope and doubt in the promise of neuroimaging: The case of autism spectrum disorder. Health (London). 2016 Jul 29 doi: 10.1177/1363459316660860. X-1
4694 Bertram J, Koschutzke L, Pfannmoller JP, . Morphological and behavioral characterization of adult mice deficient for SrGAP3. Cell Tissue Res. 2016 May 17 doi: 10.1007/s00441-016-2413-y. X-1
4695 Berzhanskaya J, Phillips MA, Gorin A, . Disrupted Cortical State Regulation in a Rat Model of Fragile X Syndrome. Cereb Cortex. 2016 Jan 5 doi: 10.1093/cercor/bhv331. X-1
4696 Besag F, Aldenkamp A, Caplan R, . Psychiatric and Behavioural Disorders in Children with Epilepsy (ILAE Task Force Report): Epilepsy and autism. Epileptic Disord. 2016 May 16 doi: 10.1684/epd.2016.0812. X-1
4697 Besag F, Gobbi G, Aldenkamp A, . Psychiatric and Behavioural Disorders in Children with Epilepsy (ILAE Task Force Report): Behavioural and psychiatric disorders associated with childhood epilepsy syndromes. Epileptic Disord. 2016 May 16 doi: 10.1684/epd.2016.0815. X-1
4698 Beunders G, van de Kamp J, Vasudevan P, . A detailed clinical analysis of 13 patients with AUTS2 syndrome further delineates the phenotypic spectrum and underscores the behavioural phenotype. J Med Genet. 2016 Apr 13 doi: 10.1136/jmedgenet-2015-103601. X-1
4699 Bhat G, LaGrave D, Millson A, . Xq11.1–11.2 deletion involving ARHGEF9 in a girl with autism spectrum disorder. Eur J Med Genet. 2016 May 27 doi: 10.1016/j.ejmg.2016.05.014. X-1
4700 Bhattacharya A, Mamcarz M, Mullins C, . Targeting Translation Control with p70 S6 Kinase 1 Inhibitors to Reverse Phenotypes in Fragile X Syndrome Mice. Neuropsychopharmacology. 2016 Jul;41(8):1991–2000. doi: 10.1038/npp.2015.369. X-126708105
4701 Bhattacharyya S. Inside story of Group I Metabotropic Glutamate Receptors (mGluRs). Int J Biochem Cell Biol. 2016 Mar 14 doi: 10.1016/j.biocel.2016.03.003. X-1, X-3
4702 Bidinosti M, Botta P, Kruttner S, . CLK2 inhibition ameliorates autistic features associated with SHANK3 deficiency. Science. 2016 Mar 11;351(6278):1199–203. doi: 10.1126/science.aad5487. X-126847545
4703 Billeci L, Tonacci A, Tartarisco G, . An Integrated Approach for the Monitoring of Brain and Autonomic Response of Children with Autism Spectrum Disorders during Treatment by Wearable Technologies. Front Neurosci. 2016;10:276. doi: 10.3389/fnins.2016.00276. X-127445652
4704 Billen J, Hashim R, Ito F. Ultrastructure of the mandibular gland of the ant Myrmoteras iriodum. Arthropod Struct Dev. 2016 May 1 doi: 10.1016/j.asd.2016.04.003. X-1
4705 Bin S, Xiangwang H, Sheng X, . Artificial Cervical Disc Replacement for the Treatment of Adjacent Segment Disease after Anterior Cervical Decompression and Fusion. Clin Spine Surg. 2016 Jun 28 doi: 10.1097/bsd.0000000000000173. X-1
4706 Biran J, Levkowitz G. Zebrafish Reel in Phenotypic Suppressors of Autism. Neuron. 2016 Feb 17;89(4):673–5. doi: 10.1016/j.neuron.2016.02.005. X-126889805
4707 Birch RC, Hocking DR, Trollor JN. Prevalence and predictors of subjective memory complaints in adult male carriers of the FMR1 premutation. Clin Neuropsychol. 2016 Jun 29:1–15. doi: 10.1080/13854046.2016.1145905. X-1
4708 Biscaldi M, Bednorz N, Weissbrodt K, . Cognitive endophenotypes of attention deficit/hyperactivity disorder and intra-subject variability in patients with autism spectrum disorder. Biol Psychol. 2016 Apr 30;118:25–34. doi: 10.1016/j.biopsycho.2016.04.064. X-127143193
4709 Bishop SL, Havdahl KA, Huerta M, . Subdimensions of social-communication impairment in autism spectrum disorder. J Child Psychol Psychiatry. 2016 Jan 8 doi: 10.1111/jcpp.12510. X-1
4710 Bishop SL, Havdahl KA, Huerta M, . Subdimensions of social-communication impairment in autism spectrum disorder. Journal of Child Psychology and Psychiatry. 2016;57(8):909–16. doi: http://dx.doi.org/10.1111/jcpp.12510. X-126748412
4711 Bishop SL, Huerta M, Gotham K, . The autism symptom interview, school-age: A brief telephone interview to identify autism spectrum disorders in 5-to-12-year-old children. Autism Res. 2016 Jun 10 doi: 10.1002/aur.1645. X-1
4712 Bishop-Fitzpatrick L, Hong J, Smith LE, . Characterizing Objective Quality of Life and Normative Outcomes in Adults with Autism Spectrum Disorder: An Exploratory Latent Class Analysis. J Autism Dev Disord. 2016 May 20 doi: 10.1007/s10803-016-2816-3. X-1
4713 Biskup CS, Helmbold K, Baurmann D, . Resting state default mode network connectivity in children and adolescents with ADHD after acute tryptophan depletion. Acta Psychiatrica Scandinavica. 2016;134(2):161–71. doi: http://dx.doi.org/10.1111/acps.12573. X-127145324
4714 Bissonette GB, Roesch MR. Development and function of the midbrain dopamine system: what we know and what we need to. Genes Brain Behav. 2016 Jan;15(1):62–73. doi: 10.1111/gbb.12257. X-126548362
4715 Bitsika V, Sharpley CF. The association between social responsivity and depression in high-functioning boys with an Autism Spectrum Disorder. Journal of Developmental and Physical Disabilities. 2016;28(2):317–31. doi: http://dx.doi.org/10.1007/s10882-015-9470-0. X-1
4716 Bitsika V, Sharpley CF, Christie DR, . Measuring Personal and Functional Changes in Prostate Cancer Survivors: Development and validation of the FADE: Data from the TROG 03.04 RADAR trial. Psychooncology. 2016 May 30 doi: 10.1002/pon.4182. X-1
4717 Bitsika V, Sharpley CF, Mills R. Are Sensory Processing Features Associated with Depressive Symptoms in Boys with an ASD? J Autism Dev Disord. 2016 Jan;46(1):242–52. doi: 10.1007/s10803-015-2569-4. X-126319255
4718 Bitsika V, Sharpley CF, Mills R. How are Sensory Features associated with seven anxiety disorders in boys with Autism Spectrum Disorder? International Journal of Developmental Neuroscience. 2016;50:47–54. doi: http://dx.doi.org/10.1016/j.ijdevneu.2016.03.005. X-126975191
4719 Bjornsdotter M, Wang N, Pelphrey K, . Evaluation of Quantified Social Perception Circuit Activity as a Neurobiological Marker of Autism Spectrum Disorder. JAMA Psychiatry. 2016 Jun 1;73(6):614–21. doi: 10.1001/jamapsychiatry.2016.0219. X-127096285
4720 Blanco-Suarez E, Caldwell AL, Allen NJ. Role of astrocyte-synapse interactions in CNS disorders. J Physiol. 2016 Jul 5 doi: 10.1113/jp270988. X-1
4721 Bland VJ, Bai JY, Fullerton JA, . Signaled alternative reinforcement and the persistence of operant behavior. J Exp Anal Behav. 2016 Jun 10 doi: 10.1002/jeab.212. X-1
4722 Blanquie O, Liebmann L, Hubner CA, . NKCC1-Mediated GABAergic Signaling Promotes Postnatal Cell Death in Neocortical Cajal-Retzius Cells. Cereb Cortex. 2016 Jan 26 doi: 10.1093/cercor/bhw004. X-1
4723 Bliksted V, Ubukata S, Koelkebeck K. Discriminating autism spectrum disorders from schizophrenia by investigation of mental state attribution on an on-line mentalizing task: A review and meta-analysis. Schizophr Res. 2016 Mar;171(1–3):16–26. doi: 10.1016/j.schres.2016.01.037. X-126817402
4724 Bo J, Lee C-M, Colbert A, . Do children with autism spectrum disorders have motor learning difficulties? Research in Autism Spectrum Disorders. 2016;23:50–62. doi: http://dx.doi.org/10.1016/j.rasd.2015.12.001. X-1, X-2
4725 Bohnert A, Lieb R, Arola N. More than Leisure: Organized Activity Participation and Socio-Emotional Adjustment Among Adolescents with Autism Spectrum Disorder. J Autism Dev Disord. 2016 May 3 doi: 10.1007/s10803-016-2783-8. X-1, X-3
4726 Boilson AM, Staines A, Ramirez A, . Operationalisation of the European Protocol for Autism Prevalence (EPAP) for Autism Spectrum Disorder Prevalence Measurement in Ireland. J Autism Dev Disord. 2016 Jun 30 doi: 10.1007/s10803-016-2837-y. X-1
4727 Bokshan SL, Godzik J, Dalton J, . Reliability of the revised Scoliosis Research Society-22 and Oswestry Disability Index (ODI) questionnaires in adult spinal deformity when administered by telephone. Spine J. 2016 Mar 17 doi: 10.1016/j.spinee.2016.03.022. X-1
4728 Bolkan S, Gordon JA. Neuroscience: Untangling autism. Nature. 2016 Apr 7;532(7597):45–6. doi: 10.1038/nature17311. X-1, X-227007842
4729 Bolkvadze T, Puhakka N, Pitkanen A. Epileptogenesis after traumatic brain injury in Plaur-deficient mice. Epilepsy Behav. 2016 Jul;60:187–96. doi: 10.1016/j.yebeh.2016.04.038. X-127208924
4730 Bonatto SJ, Kerner M, Merelles S, . The prevalence of symptoms of attention-deficit/hyperactivity disorder in parents of children with autism spectrum disorder. Psychiatry Research. 2016;240:1–3. doi: http://dx.doi.org/10.1016/j.psychres.2016.04.006. X-127060874
4731 Bone D, Bishop S, Black MP, . Use of machine learning to improve autism screening and diagnostic instruments: effectiveness, efficiency, and multi-instrument fusion. J Child Psychol Psychiatry. 2016 Apr 19 doi: 10.1111/jcpp.12559. X-1
4732 Bone D, Bishop SL, Black MP, . Use of machine learning to improve autism screening and diagnostic instruments: Effectiveness, efficiency, and multi-instrument fusion. Journal of Child Psychology and Psychiatry. 2016;57(8):927–37. doi: http://dx.doi.org/10.1111/jcpp.12559. X-127090613
4733 Bono V, Narzisi A, Jouen A-L, . GOLIAH: A gaming platform for home-based intervention in autism—Principles and design. Frontiers in Psychiatry. 2016;7. X-1, X-3, X-426858659
4734 Booms S, Hill E, Kulhanek L, . Iodine Deficiency and Hypothyroidism From Voluntary Diet Restrictions in the US: Case Reports. Pediatrics. 2016 Jun;137(6)doi: 10.1542/peds.2015-4003. X-1
4735 Boonen S, Billen J. Functional morphology of the maxillary and propharyngeal glands of Monomorium pharaonis (L.). Arthropod Struct Dev.. 2016 May 15 doi: 10.1016/j.asd.2016.04.005. X-1
4736 Booth RD, Happe FG. Evidence of Reduced Global Processing in Autism Spectrum Disorder. J Autism Dev Disord. 2016 Feb 10 doi: 10.1007/s10803-016-2724-6. X-1
4737 Bos PA, Hofman D, Hermans EJ, . Testosterone reduces functional connectivity during the ‘Reading the Mind in the Eyes’ Test. Psychoneuroendocrinology. 2016 Jun;68:194–201. doi: 10.1016/j.psyneuen.2016.03.006. X-126994483
4738 Bostrom C, Yau SY, Majaess N, . Hippocampal Dysfunction and Cognitive Impairment in Fragile-X Syndrome. Neurosci Biobehav Rev. 2016 Jun 23 doi: 10.1016/j.neubiorev.2016.06.033. X-1
4739 Bottema-Beutel K. Associations between joint attention and language in autism spectrum disorder and typical development: A systematic review and meta-regression analysis. Autism Res. 2016 Apr 5 doi: 10.1002/aur.1624. X-1
4740 Bottema-Beutel K, Turiel E, DeWitt MN, . To include or not to include: Evaluations and reasoning about the failure to include peers with autism spectrum disorder in elementary students. Autism. 2016 Mar 7 doi: 10.1177/1362361315622412. X-1
4741 Bouck EC, Satsangi R, Bartlett W. Comparing a number line and audio prompts in supporting price comparison by students with intellectual disability. Res Dev Disabil. 2016 Jun–Jul;53–54:342–57. doi: 10.1016/j.ridd.2016.02.011. X-1
4742 Boujut E, Dean A, Grouselle A, . Comparative Study of Teachers in Regular Schools and Teachers in Specialized Schools in France, Working with Students with an Autism Spectrum Disorder: Stress, Social Support, Coping Strategies and Burnout. J Autism Dev Disord. 2016 Jun 9 doi: 10.1007/s10803-016-2833-2. X-1
4743 Boukhris T, Sheehy O, Mottron L, . Antidepressant Use During Pregnancy and the Risk of Autism Spectrum Disorder in Children. JAMA Pediatr. 2016 Feb;170(2):117–24. doi: 10.1001/jamapediatrics.2015.3356. X-126660917
4744 Bourgeois JA. Neuropsychiatry of fragile X-premutation carriers with and without fragile X-associated tremor-ataxia syndrome: implications for neuropsychology. Clin Neuropsychol. 2016 Jun 29:1–16. doi: 10.1080/13854046.2016.1192134. X-1
4745 Bourgeron T. Current knowledge on the genetics of autism and propositions for future research. C R Biol. 2016 Jun 8 doi: 10.1016/j.crvi.2016.05.004. X-1
4746 Bourgeron T. The genetics and neurobiology of ESSENCE: The third Birgit Olsson lecture. Nord J Psychiatry. 2016;70(1):1–9. doi: 10.3109/08039488.2015.1042519. X-125971862
4747 Bouvet L, Mottron L, Valdois S, . Auditory stream segregation in autism spectrum disorder: Benefits and downsides of superior perceptual processes. Journal of Autism and Developmental Disorders. 2016;46(5):1553–61. doi: http://dx.doi.org/10.1007/s10803-013-2003-8. X-124281422
4748 Bowman P, Broadbridge E, Knight BA, . Psychiatric morbidity in children with KCNJ11 neonatal diabetes. Diabet Med. 2016 Apr 18 doi: 10.1111/dme.13135. X-1
4749 Boyer BE, Doove LL, Geurts HM, . Qualitative Treatment-Subgroup Interactions in a Randomized Clinical Trial of Treatments for Adolescents with ADHD: Exploring What Cognitive-Behavioral Treatment Works for Whom. PLoS One. 2016;11(3):e0150698. doi: 10.1371/journal.pone.0150698. X-126977602
4750 Bozkus-Genc G, Yucesoy-Ozkan S. Meta-analysis of pivotal response training for children with autism spectrum disorder. Education and Training in Autism and Developmental Disabilities. 2016;51(1):13–26. X-2
4751 Bozzatello P, Brignolo E, De Grandi E, . Supplementation with Omega-3 Fatty Acids in Psychiatric Disorders: A Review of Literature Data. J Clin Med. 2016;5(8)doi: 10.3390/jcm5080067. X-1, X-2
4752 Brabson LA, Brown JL, Capriotti MR, . Patterned changes in urge ratings with tic suppression in youth with chronic tic disorders. Journal of Behavior Therapy and Experimental Psychiatry. 2016;50:162–70. doi: http://dx.doi.org/10.1016/j.jbtep.2015.07.004. X-126255052
4753 Braddock BA, Gabany C, Shah M, . Patterns of Gesture Use in Adolescents With Autism Spectrum Disorder. Am J Speech Lang Pathol. 2016 Jun 3:1–8. doi: 10.1044/2015_ajslp-14-0112. X-1
4754 Braddock BA, Hilton JC. Arm and hand movement in children suspected of having autism spectrum disorder. Communication Disorders Quarterly. 2016;37(3):148–59. doi: http://dx.doi.org/10.1177/1525740114562065. X-1
4755 Bradley CC, Boan AD, Cohen AP, . Reported History of Developmental Regression and Restricted, Repetitive Behaviors in Children with Autism Spectrum Disorders. J Dev Behav Pediatr. 2016 Jul–Aug;37(6):451–6. doi: 10.1097/dbp.0000000000000316. X-127366956
4756 Bradstreet LE, Juechter JI, Kamphaus RW, . Using the BASC-2 Parent Rating Scales to Screen for Autism Spectrum Disorder in Toddlers and Preschool-Aged Children. J Abnorm Child Psychol. 2016 May 14 doi: 10.1007/s10802-016-0167-3. X-1
4757 Brady LJ, Bartley AF, Li Q, . Transcriptional dysregulation causes altered modulation of inhibition by haloperidol. Neuropharmacology. 2016 Jul 29 doi: 10.1016/j.neuropharm.2016.07.034. X-1
4758 Branigan HP, Tosi A, Gillespie-Smith K. Spontaneous Lexical Alignment in Children With an Autistic Spectrum Disorder and Their Typically Developing Peers. J Exp Psychol Learn Mem Cogn. 2016 Apr 14 doi: 10.1037/xlm0000272. X-1
4759 Breckpot J, Vercruyssen M, Weyts E, . Copy number variation analysis in adults with catatonia confirms haploinsufficiency of SHANK3 as a predisposing factor. Eur J Med Genet. 2016 Aug 9;59(9):436–43. doi: 10.1016/j.ejmg.2016.08.003. X-127519580
4760 Bremer E, Crozier M, Lloyd M. A systematic review of the behavioural outcomes following exercise interventions for children and youth with autism spectrum disorder. Autism. 2016 Jan 28 doi: 10.1177/1362361315616002. X-1, X-2
4761 Brett D, Warnell F, McConachie H, . Factors affecting age at ASD diagnosis in UK: No evidence that diagnosis age has decreased between 2004 and 2014. Journal of Autism and Developmental Disorders. 2016;46(6):1974–84. doi: http://dx.doi.org/10.1007/s10803-016-2716-6. X-127032954
4762 Breuillard D, Leunen D, Chemaly N, . Autism spectrum disorder phenotype and intellectual disability in females with epilepsy and PCDH-19 mutations. Epilepsy & Behavior. 2016;60:75–80. doi: http://dx.doi.org/10.1016/j.yebeh.2016.04.009. X-127179713
4763 Brewer CC, Zalewski CK, King KA, . Heritability of non-speech auditory processing skills. Eur J Hum Genet. 2016 Feb 17 doi: 10.1038/ejhg.2015.277. X-1
4764 Brewer N, Zoanetti J, Young RL. The influence of media suggestions about links between criminality and autism spectrum disorder. Autism. 2016 Apr 30 doi: 10.1177/1362361316632097. X-1
4765 Brignell A, Williams K, Prior M, . Parent-reported patterns of loss and gain in communication in 1- to 2-year-old children are not unique to autism spectrum disorder. Autism. 2016 May 12 doi: 10.1177/1362361316644729. X-1
4766 Brockman M, Hussain K, Sanchez B, . Managing child behavior problems in children with Autism Spectrum Disorders: Utilizing structural and solution focused therapy with primary caregivers. American Journal of Family Therapy. 2016;44(1):1–10. doi: http://dx.doi.org/10.1080/01926187.2015.1099414. X-1, X-2, X-3, X-4
4767 Brodhead MT, Al-Dubayan MN, Mates M, . An evaluation of a brief video-based multiple-stimulus without replacement preference assessment. Behavior Analysis in Practice. 2016;9(2):160–4. doi: http://dx.doi.org/10.1007/s40617-015-0081-0. X-1, X-427606245
4768 Brodhead MT, Higbee TS, Gerencser KR, . The use of a discrimination-training procedure to teach mand variability to children with autism. Journal of Applied Behavior Analysis. 2016;49(1):34–48. doi: http://dx.doi.org/10.1002/jaba.280. X-1,X-3, X-426696376
4769 Broek JA, Lin Z, de Gruiter HM, . Synaptic vesicle dynamic changes in a model of fragile X. Mol Autism. 2016;7:17. doi: 10.1186/s13229-016-0080-1. X-126933487
4770 Bromley R. The treatment of epilepsy in pregnancy: The neurodevelopmental risks associated with exposure to antiepileptic drugs. Reprod Toxicol. 2016 Jun 14 doi: 10.1016/j.reprotox.2016.06.007. X-1
4771 Brook K. A response to ‘Notes on a Puzzle Piece’. Autism. 2016 Feb;20(2):251–2. doi: 10.1177/1362361315604077. X-126408633
4772 Brown JA, Woods JJ. Parent-implemented communication intervention: Sequential analysis of triadic relationships. Topics in Early Childhood Special Education. 2016;36(2):115–24. doi: http://dx.doi.org/10.1177/0271121416628200. X-1, X-3, X-4
4773 Brown RC, Nugent NR, Hawn SE, . Predicting the Transition From Acute Stress Disorder to Posttraumatic Stress Disorder in Children With Severe Injuries. J Pediatr Health Care. 2016 Jan 14 doi: 10.1016/j.pedhc.2015.11.015. X-1
4774 Bruckheimer E, Rotschild C, Dagan T, . Computer-generated real-time digital holography: first time use in clinical medical imaging. Eur Heart J Cardiovasc Imaging. 2016 Jun 9 doi: 10.1093/ehjci/jew087. X-1
4775 Brukner-Wertman Y, Laor N, Golan O. Social (Pragmatic) Communication Disorder and Its Relation to the Autism Spectrum: Dilemmas Arising From the DSM-5 Classification. J Autism Dev Disord. 2016 May 26 doi: 10.1007/s10803-016-2814-5. X-1
4776 Bruno JL, Hosseini SM, Saggar M, . Altered Brain Network Segregation in Fragile X Syndrome Revealed by Structural Connectomics. Cereb Cortex. 2016 Mar 22 doi: 10.1093/cercor/bhw055. X-1
4777 Bryant CD, Yazdani N. RNA-binding proteins, neural development and the addictions. Genes Brain Behav. 2016 Jan;15(1):169–86. doi: 10.1111/gbb.12273. X-126643147
4778 Buckland AJ, Vira S, Oren JH, . When is compensation for lumbar spinal stenosis a clinical sagittal plane deformity? Spine J. 2016 Apr 5 doi: 10.1016/j.spinee.2016.03.047. X-1
4779 Bueno C, Tabares-Seisdedos R, Moraleda JM, . Rett Syndrome Mutant Neural Cells Lacks MeCP2 Immunoreactive Bands. PLoS One. 2016;11(4):e0153262. doi: 10.1371/journal.pone.0153262. X-127064487
4780 Buffington SA, Di Prisco GV, Auchtung TA, . Microbial Reconstitution Reverses Maternal Diet-Induced Social and Synaptic Deficits in Offspring. Cell. 2016 Jun 16;165(7):1762–75. doi: 10.1016/j.cell.2016.06.001. X-127315483
4781 Bulkeley K, Bundy A, Roberts J, . Family-Centered Management of Sensory Challenges of Children With Autism: Single-Case Experimental Design. Am J Occup Ther. 2016 Sep–Oct;70(5):7005220040p1–8. doi: 10.5014/ajot.2016.017822. X-3, X-4
4782 Bull LE, Oliver C, Woodcock KA. Signalling changes to individuals who show resistance to change can reduce challenging behaviour. J Behav Ther Exp Psychiatry. 2016 Jun 22;54:58–70. doi: 10.1016/j.jbtep.2016.06.006. X-127367567
4783 Bultas MW, Johnson NL, Burkett K, . Translating Research to Practice for Children With Autism Spectrum Disorder: Part 2: Behavior Management in Home and Health Care Settings. J Pediatr Health Care. 2016 Jan–Feb;30(1):27–37. doi: 10.1016/j.pedhc.2015.09.009. X-126525946
4784 Bultas MW, McMillin SE, Zand DH. Reducing Barriers to Care in the Office-Based Health Care Setting for Children With Autism. J Pediatr Health Care. 2016 Jan–Feb;30(1):5–14. doi: 10.1016/j.pedhc.2015.08.007. X-126455786
4785 Bulut MO, Yucel IK, Kucuk M, . Initial Experience with the Nit-Occlud ASD-R: Short-Term Results. Pediatr Cardiol. 2016 Jun 9 doi: 10.1007/s00246-016-1426-3. X-1
4786 Burbach JP. AUTISM. Unraveling a pathway to autism. Science. 2016 Mar 11;351(6278):1153–4. doi: 10.1126/science.aaf5097. X-1, X-226965613
4787 Burger-Caplan R, Saulnier C, Jones W, . Predicting social and communicative ability in school-age children with autism spectrum disorder: A pilot study of the Social Attribution Task, Multiple Choice. Autism. 2016 Apr 27 doi: 10.1177/1362361315617589. X-1
4788 Burger-Veltmeijer AEJ, Minnaert AEMG, Van den Bosch EJ. Intellectually gifted students with possible characteristics of ASD: A multiple case study of psycho-educational assessment practices. European Journal of Special Needs Education. 2016;31(1):76–95. doi: http://dx.doi.org/10.1080/08856257.2015.1087147. X-1
4789 Burke M, Heller T. Individual, parent and social-environmental correlates of caregiving experiences among parents of adults with autism spectrum disorder. J Intellect Disabil Res. 2016 May;60(5):401–11. doi: 10.1111/jir.12271. X-127120984
4790 Burke MM, Magana S, Garcia M, . Brief Report: The Feasibility and Effectiveness of an Advocacy Program for Latino Families of Children with Autism Spectrum Disorder. J Autism Dev Disord. 2016 Jul;46(7):2532–8. doi: 10.1007/s10803-016-2765-x. X-126944592
4791 Burkhardt BW, Brielmaier M, Schwerdtfeger K, . Smith-Robinson Procedure with an Autologus Iliac Crest for Degenerative Cervical Disc Disease A 28-year Follow-Up of 95 Patients. World Neurosurg. 2016 May 26 doi: 10.1016/j.wneu.2016.05.036. X-1
4792 Burkhardt BW, Brielmeier M, Schwerdtfeger K, . 311 Smith-Robinson Procedure With an Autologous Iliac Crest Bone Graft With and Without Caspar Plating as a Treatment for Soft Cervical Disc Herniation: Report of 122 Patients With an Average Follow-up of 25 Years. Neurosurgery. 2016 Aug;63 Suppl 1:189–90. doi: 10.1227/01.neu.0000489800.11738.0d. X-1
4793 Burns CO, Matson JL, Cervantes PE, . Hearing impairment, autism spectrum disorder, and developmental functioning in infants and toddlers. Journal of Developmental and Physical Disabilities. 2016;28(4):495–507. doi: http://dx.doi.org/10.1007/s10882-016-9486-0. X-1
4794 Burrows CA, Laird AR, Uddin LQ. Functional connectivity of brain regions for self- and other-evaluation in children, adolescents and adults with autism. Dev Sci. 2016 Jan 11 doi: 10.1111/desc.12400. X-1, X-2, X-3
4795 Burrows CA, Laird AR, Uddin LQ. Functional connectivity of brain regions for self- and other-evaluation in children, adolescents and adults with autism. Developmental Science. 2016;19(4):564–80. doi: http://dx.doi.org/10.1111/desc.12400. X-126750447
4796 Burrows CA, Usher LV, Schwartz CB, . Supporting the spectrum hypothesis: Self-reported temperament in children and adolescents with high functioning autism. Journal of Autism and Developmental Disorders. 2016;46(4):1184–95. doi: http://dx.doi.org/10.1007/s10803-015-2653-9. X-126589536
4797 Burt SA, Klump KL, Gorman-Smith D, . Neighborhood disadvantage alters the origins of children’s nonaggressive conduct problems. Clinical Psychological Science. 2016;4(3):511–26. doi: http://dx.doi.org/10.1177/2167702615618164. X-127347447
4798 Burton CL, Crosbie J, Dupuis A, . Clinical correlates of hoarding with and without comorbid obsessive-compulsive symptoms in a community pediatric sample. Journal of the American Academy of Child & Adolescent Psychiatry. 2016;55(2):114–21. doi: http://dx.doi.org/10.1016/j.jaac.2015.11.014. X-126802778
4799 Butera G, Lovin N, Basile DP. How to deal with atrial septal defect closure from right internal jugular vein: Role of venous-arterial circuit for sizing and over-the-wire device implantation. Catheter Cardiovasc Interv. 2016 Jun 17 doi: 10.1002/ccd.26621. X-1
4800 Butera G, Lovin N, Basile DP. Patent ductus arteriosus balloon sizing: A new technique to evaluate the size in complex cases. Catheter Cardiovasc Interv. 2016 May;87(6):1135–7. doi: 10.1002/ccd.26331. X-126602995
4801 Cadette JN, Wilson CL, Brady MP, . The Effectiveness of Direct Instruction in Teaching Students with Autism Spectrum Disorder to Answer “Wh-” Questions. J Autism Dev Disord. 2016 Jun 16 doi: 10.1007/s10803-016-2825-2. X-1, X-3, X-4
4802 Caeyenberghs K, Taymans T, Wilson PH, . Neural signature of developmental coordination disorder in the structural connectome independent of comorbid autism. Dev Sci. 2016 May 4 doi: 10.1111/desc.12424. X-1
4803 Cage E, Bird G, Pellicano L. ‘I am who I am’: Reputation concerns in adolescents on the autism spectrum. Research in Autism Spectrum Disorders. 2016;25:12–23. doi: http://dx.doi.org/10.1016/j.rasd.2016.01.010. X-1
4804 Cai J, Ding L, Zhang J-S, . Elevated plasma levels of glutamate in children with autism spectrum disorders. NeuroReport: For Rapid Communication of Neuroscience Research. 2016;27(4):272–6. doi: http://dx.doi.org/10.1097/WNR.0000000000000532. X-1
4805 Cairns J, Swanson D, Yeung J, . Abnormalities in the Structure and Function of Cerebellar Neurons and Neuroglia in the Lc/+ Chimeric Mouse Model of Variable Developmental Purkinje Cell Loss. Cerebellum. 2016 Feb 2 doi: 10.1007/s12311-015-0756-7. X-1
4806 Call NA, Alvarez JP, Simmons CA, . Clinical outcomes of behavioral treatments for elopement in individuals with autism spectrum disorder and other developmental disabilities. Autism. 2016 May 12 doi: 10.1177/1362361316644732. X-1, X-3
4807 Campbell SB, Leezenbaum NB, Mahoney AS, . Pretend play and social engagement in toddlers at high and low genetic risk for autism spectrum disorder. Journal of Autism and Developmental Disorders. 2016;46(7):2305–16. doi: http://dx.doi.org/10.1007/s10803-016-2764-y. X-126931334
4808 Campione GC, Piazza C, Villa L, . Three-Dimensional Kinematic Analysis of Prehension Movements in Young Children with Autism Spectrum Disorder: New Insights on Motor Impairment. J Autism Dev Disord. 2016 Jun;46(6):1985–99. doi: 10.1007/s10803-016-2732-6. X-126861718
4809 Campistol J, Diez-Juan M, Callejon L, . Inborn error metabolic screening in individuals with nonsyndromic autism spectrum disorders. Dev Med Child Neurol. 2016 Mar 31 doi: 10.1111/dmcn.13114. X-1
4810 Campos LK, Fernandes FD. School profile and language and cognitive abilities of children and adolescents with autism spectrum disorders. Codas. 2016 Jun 16;0:0. doi: 10.1590/2317-1782/20162015023. X-1
4811 Canals J, Morales-Hidalgo P, Jane MC, . ADHD Prevalence in Spanish Preschoolers: Comorbidity, Socio- Demographic Factors, and Functional Consequences. J Atten Disord. 2016 Mar 23 doi: 10.1177/1087054716638511. X-1
4812 Candini M, Giuberti V, Manattini A, . Personal space regulation in childhood autism: Effects of social interaction and person’s perspective. Autism Res. 2016 May 9 doi: 10.1002/aur.1637. X-1
4813 Canfield AR, Eigsti IM, de Marchena A, . Story Goodness in Adolescents With Autism Spectrum Disorder (ASD) and in Optimal Outcomes From ASD. J Speech Lang Hear Res. 2016 Jun 1;59(3):533–45. doi: 10.1044/2015_jslhr-l-15-0022. X-127280731
4814 Cantio C, Jepsen JR, Madsen GF, . Exploring ‘The autisms’ at a cognitive level. Autism Res. 2016 Apr 19 doi: 10.1002/aur.1630. X-1
4815 Cao Y, Wang J, Wei C, . Genetic variations of NKX2-5 in sporadic atrial septal defect and ventricular septal defect in Chinese Yunnan population. Gene. 2016 Jan 1;575(1):29–33. doi: 10.1016/j.gene.2015.08.033. X-126297999
4816 Capriola NN, Maddox BB, White SW. No Offense Intended: Fear of Negative Evaluation in Adolescents and Adults with Autism Spectrum Disorder. J Autism Dev Disord. 2016 Jun 20 doi: 10.1007/s10803-016-2827-0. X-1
4817 Carbone PS, Norlin C, Young PC. Improving Early Identification and Ongoing Care of Children With Autism Spectrum Disorder. Pediatrics. 2016 Jun;137(6)doi: 10.1542/peds.2015-1850. X-1
4818 Cariveau T, Kodak T, Campbell V. The effects of intertrial interval and instructional format on skill acquisition and maintenance for children with autism spectrum disorders. J Appl Behav Anal. 2016 May 26 doi: 10.1002/jaba.322. X-1
4819 Carr ME. Self-management of challenging behaviours associated with autism spectrum disorder: A meta-analysis. Australian Psychologist. 2016;51(4):316–33. doi: http://dx.doi.org/10.1111/ap.12227. X-2
4820 Carr T, Lord C. A Pilot Study Promoting Participation of Families with Limited Resources in Early Autism Intervention. Res Autism Spectr Disord. 2016 May 1;2:87–96. doi: 10.1016/j.rasd.2016.02.003. X-127019670
4821 Carrigan N, Allez K. Cognitive Behaviour Therapy for Post-Traumatic Stress Disorder in a person with an Autism Spectrum Condition and Intellectual Disability: A Case Study. J Appl Res Intellect Disabil. 2016 Feb 12 doi: 10.1111/jar.12243. X-1, X-3
4822 Carroll RA, Kodak T, Adolf KJ. Effect of delayed reinforcement on skill acquisition during discrete-trial instruction: Implications for treatment-integrity errors in academic settings. Journal of Applied Behavior Analysis. 2016;49(1):176–81. doi: http://dx.doi.org/10.1002/jaba.268. X-3, X-426947579
4823 Carson TB, Wilkes BJ, Patel K, . Vestibulo-ocular reflex function in children with high-functioning autism spectrum disorders. Autism Res. 2016 May 25 doi: 10.1002/aur.1642. X-1
4824 Carter CJ. The barrier, airway particle clearance, placental and detoxification functions of autism susceptibility genes. Neurochem Int. 2016 Jun 11;99:42–51. doi: 10.1016/j.neuint.2016.06.003. X-127296113
4825 Casanova EL, Sharp JL, Chakraborty H, . Genes with high penetrance for syndromic and non-syndromic autism typically function within the nucleus and regulate gene expression. Mol Autism. 2016;7:18. doi: 10.1186/s13229-016-0082-z. X-126985359
4826 Casartelli L, Chiamulera C. The motor way: Clinical implications of understanding and shaping actions with the motor system in autism and drug addiction. Cogn Affect Behav Neurosci. 2016 Apr;16(2):191–206. doi: 10.3758/s13415-015-0399-7. X-126679723
4827 Cascia J, Barr JJ. Associations Among Vocabulary, Executive Function Skills and Empathy in Individuals with Autism Spectrum Disorder. J Appl Res Intellect Disabil. 2016 May 2 doi: 10.1111/jar.12257. X-1
4828 Cascio CJ, Woynaroski T, Baranek GT, . Toward an interdisciplinary approach to understanding sensory function in autism spectrum disorder. Autism Res. 2016 Apr 19 doi: 10.1002/aur.1612. X-1
4829 Case LK, Laubacher CM, Olausson H, . Encoding of Touch Intensity But Not Pleasantness in Human Primary Somatosensory Cortex. J Neurosci. 2016 May 25;36(21):5850–60. doi: 10.1523/jneurosci.1130-15.2016. X-127225773
4830 Casella G, Bordo BM, Schalling R, . Neurological disorders and celiac disease. Minerva Gastroenterol Dietol. 2016 Apr 6. X-1
4831 Cashin A. Autism Spectrum Disorder and Psychosis: A Case Study. J Child Adolesc Psychiatr Nurs. 2016 Jun 17 doi: 10.1111/jcap.12145. X-1
4832 Cassidy SA, Stenger B, Van Dongen L, . Expressive visual text-to-speech as an assistive technology for individuals with autism spectrum conditions. Comput Vis Image Underst. 2016 Jul;148:193–200. doi: 10.1016/j.cviu.2015.08.011. X-127375348
4833 Castro K, Baronio D, Perry IS, . The effect of ketogenic diet in an animal model of autism induced by prenatal exposure to valproic acid. Nutr Neurosci. 2016 Feb 9 doi: 10.1080/1028415x.2015.1133029. X-1
4834 Castro VM, Kong SW, Clements CC, . Absence of evidence for increase in risk for autism or attention-deficit hyperactivity disorder following antidepressant exposure during pregnancy: a replication study. Transl Psychiatry. 2016;6:e708. doi: 10.1038/tp.2015.190. X-126731445
4835 Catani M, Dell’Acqua F, Budisavljevic S, . Frontal networks in adults with autism spectrum disorder. Brain. 2016 Feb;139(Pt 2):616–30. doi: 10.1093/brain/awv351. X-126912520
4836 Çelik G, Taş D, Tahiroğlu A, . Vitamin D deficiency in obsessive–compulsive disorder patients with pediatric autoimmune neuropsychiatric disorders associated with streptococcal infections: A case control study. Nöropsikiyatri Arşivi / Archives of Neuropsychiatry. 2016;53(1):33–7. doi: http://dx.doi.org/10.5152/npa.2015.8763. X-128360763
4837 Cengher M, Shamoun K, Moss P, . A comparison of the effects of two prompt-fading strategies on skill acquisition in children with autism spectrum disorders. Behavior Analysis in Practice. 2016;9(2):115–25. doi: http://dx.doi.org/10.1007/s40617-015-0096-6. X-3, X-427606243
4838 Cesta CE, Mansson M, Palm C, . Polycystic ovary syndrome and psychiatric disorders: Co-morbidity and heritability in a nationwide Swedish cohort. Psychoneuroendocrinology. 2016 Aug 3;73:196–203. doi: 10.1016/j.psyneuen.2016.08.005. X-127513883
4839 Cetin I, Tezdig I, Tarakcioglu MC, . Serum levels of glial fibrillary acidic protein and Nogo-A in children with autism spectrum disorders. Biomarkers. 2016 Apr 21:1–5. doi: 10.3109/1354750x.2016.1171901. X-126643755
4840 Chaaya M, Saab D, Maalouf FT, . Prevalence of autism spectrum disorder in nurseries in Lebanon: A cross sectional study. Journal of Autism and Developmental Disorders. 2016;46(2):514–22. doi: http://dx.doi.org/10.1007/s10803-015-2590-7. X-126362151
4841 Chambers N, Stronach ST, Wetherby AM. Performance of South African children on the Communication and Symbolic Behavior Scales—Developmental Profile (CSBS DP). International Journal of Language & Communication Disorders. 2016;51(3):265–75. doi: http://dx.doi.org/10.1111/1460-6984.12203. X-126542094
4842 Chambers NJ, Wetherby AM, Stronach ST, . Early detection of autism spectrum disorder in young isiZulu-speaking children in South Africa. Autism. 2016 Jun 22 doi: 10.1177/1362361316651196. X-1
4843 Chamie F, Maia J, Giuliano LC. Device-in-device: A transcatheter alternative to surgical explantation of a failing atrial septal defect intracardiac prosthesis. Catheter Cardiovasc Interv. 2016 Feb 19 doi: 10.1002/ccd.26456. X-1
4844 Chan JS, Langer A, Kaiser J. Temporal integration of multisensory stimuli in autism spectrum disorder: a predictive coding perspective. J Neural Transm (Vienna). 2016 Jun 20 doi: 10.1007/s00702-016-1587-5. X-1
4845 Chandler S, Howlin P, Simonoff E, . Comparison of parental estimate of developmental age with measured IQ in children with neurodevelopmental disorders. Child: Care, Health and Development. 2016;42(4):486–93. doi: http://dx.doi.org/10.1111/cch.12346. X-1
4846 Chang AD, Berges VA, Chung SJ, . High-Frequency Stimulation at the Subthalamic Nucleus Suppresses Excessive Self-Grooming in Autism-Like Mouse Models. Neuropsychopharmacology. 2016 Jun;41(7):1813–21. doi: 10.1038/npp.2015.350. X-126606849
4847 Chang J, Go YY, Park MK, . Asian Sand Dust Enhances the Inflammatory Response and Mucin Gene Expression in the Middle Ear. Clin Exp Otorhinolaryngol. 2016 Apr 20 doi: 10.21053/ceo.2015.01060. X-1
4848 Chang YC, Shire SY, Shih W, . Preschool Deployment of Evidence-Based Social Communication Intervention: JASPER in the Classroom. J Autism Dev Disord. 2016 Jun;46(6):2211–23. doi: 10.1007/s10803-016-2752-2. X-126936161
4849 Chang Y-C, Locke J. A systematic review of peer-mediated interventions for children with autism spectrum disorder. Research in Autism Spectrum Disorders. 2016;27:1–10. doi: http://dx.doi.org/10.1016/j.rasd.2016.03.010. X-227807466
4850 Chang Y-C, Shih W, Kasari C. Friendships in preschool children with autism spectrum disorder: What holds them back, child characteristics or teacher behavior? Autism. 2016;20(1):65–74. doi: http://dx.doi.org/10.1177/1362361314567761. X-125694583
4851 Chang YS, Owen JP, Pojman NJ, . Reciprocal white matter alterations due to 16p11.2 chromosomal deletions versus duplications. Hum Brain Mapp.. 2016 May 24 doi: 10.1002/hbm.23211. X-1
4852 Charlson FJ, Baxter AJ, Dua T, . Excess Mortality from Mental, Neurological, and Substance Use Disorders in the Global Burden of Disease Study 2010. In: Patel V, Chisholm D, Dua T, Laxminarayan R, Medina-Mora ME, eds. Mental, Neurological, and Substance Use Disorders: Disease Control Priorities, Third Edition (Volume 4). Washington (DC): The International Bank for Reconstruction and Development / The World Bank (c) 2016 International Bank for Reconstruction and Development / The World Bank.; 2016.
4853 Charman T, Chakrabarti B. Commentary: Not just genes--reclaiming a role for environmental influences on aetiology and outcome in autism. A commentary on Mandy and Lai (2016). J Child Psychol Psychiatry. 2016 Mar;57(3):293–5. doi: 10.1111/jcpp.12527. X-126889893
4854 Chawarska K, Macari S, Powell K, . Enhanced social attention in female infant siblings at risk for autism. Journal of the American Academy of Child & Adolescent Psychiatry. 2016;55(3):188–95. doi: http://dx.doi.org/10.1016/j.jaac.2015.11.016. X-126903252
4855 Chawarska K, Ye S, Shic F, . Multilevel differences in spontaneous social attention in toddlers with autism spectrum disorder. Child Development. 2016;87(2):543–57. doi: http://dx.doi.org/10.1111/cdev.12473. X-126682668
4856 Chebli SS, Lanovaz MJ. Using computer tablets to assess preference for videos in children with autism. Behavior Analysis in Practice. 2016;9(1):50–3. doi: http://dx.doi.org/10.1007/s40617-016-0109-0. X-127606238
4857 Chen C, Hung AY, Fan YT, . Linkage between pain sensitivity and empathic response in adolescents with autism spectrum conditions and conduct disorder symptoms. Autism Res. 2016 Jun 16 doi: 10.1002/aur.1653. X-1
4858 Chen C, Van Horn JD. Developmental neurogenetics and multimodal neuroimaging of sex differences in autism. Brain Imaging Behav. 2016 Jan 19 doi: 10.1007/s11682-015-9504-3. X-1
4859 Chen CA, Bosch DG, Cho MT, . The expanding clinical phenotype of Bosch-Boonstra-Schaaf optic atrophy syndrome: 20 new cases and possible genotype-phenotype correlations. Genet Med. 2016 Mar 17 doi: 10.1038/gim.2016.18. X-1
4860 Chen C-H, Lee IJ, Lin L-Y. Augmented reality-based video-modeling storybook of nonverbal facial cues for children with autism spectrum disorder to improve their perceptions and judgments of facial expressions and emotions. Computers in Human Behavior. 2016;51(Part A):477–85. doi: http://dx.doi.org/10.1016/j.chb.2015.09.033. X-1, X-3
4861 Chen F. Risperidone-Induced Acute Respiratory Distress in an Adolescent with Autism. J Child Adolesc Psychopharmacol. 2016 May 24 doi: 10.1089/cap.2016.0051. X-1
4862 Chen H, Duan X, Liu F, . Multivariate classification of autism spectrum disorder using frequency-specific resting-state functional connectivity--A multi-center study. Prog Neuropsychopharmacol Biol Psychiatry. 2016 Jan 4;64:1–9. doi: 10.1016/j.pnpbp.2015.06.014. X-126148789
4863 Chen H, Duan X, Liu F, . Multivariate classification of autism spectrum disorder using frequency-specific resting-state functional connectivity—A multi-center study. Progress in Neuro-Psychopharmacology & Biological Psychiatry. 2016;64:1–9. doi: http://dx.doi.org/10.1016/j.pnpbp.2015.06.014. X-126148789
4864 Chen H, Zhao B, Porges EC, . Edgewise and subgraph-level tests for brain networks. Stat Med. 2016 Jul 11 doi: 10.1002/sim.7039. X-1
4865 Chen J, Qi B, Zhao J, . A novel mutation of GATA4 (K300T) associated with familial atrial septal defect. Gene. 2016 Jan 10;575(2 Pt 2):473–7. doi: 10.1016/j.gene.2015.09.021. X-126376067
4866 Chen PJ, Gau SS, Lee SH, . Differences in age-dependent neural correlates of semantic processing between youths with autism spectrum disorder and typically developing youths. Autism Res. 2016 Feb 21 doi: 10.1002/aur.1616. X-1
4867 Chen R, Nixon E, Herskovits E. Advanced Connectivity Analysis (ACA): A large scale functional connectivity data mining environment. Neuroinformatics. 2016;14(2):191–9. doi: http://dx.doi.org/10.1007/s12021-015-9290-5. X-126662457
4868 Chen SF, Chien YL, Wu CT, . Deficits in executive functions among youths with autism spectrum disorders: An age-stratified analysis. Psychological Medicine. 2016;46(8):1625–38. doi: http://dx.doi.org/10.1017/S0033291715002238. X-126997535
4869 Chen S-w, Zhong X-s, Jiang L-n, . Maternal autoimmune diseases and the risk of autism spectrum disorders in offspring: A systematic review and meta-analysis. Behavioural Brain Research. 2016;296:61–9. doi: http://dx.doi.org/10.1016/j.bbr.2015.08.035. X-126327239
4870 Chen XL, Guan L, Liu YZ, . Interspinous dynamic stabilization adjacent to fusion versus double-segment fusion for treatment of lumbar degenerative disease with a minimum follow-up of three years. Int Orthop. 2016 Jun;40(6):1275–83. doi: 10.1007/s00264-016-3199-y. X-127118374
4871 Chen Y, Wang S, Wang S, . Sodium Lauryl Sulfate Competitively Interacts with HPMC-AS and Consequently Reduces Oral Bioavailability of Posaconazole/HPMC-AS Amorphous Solid Dispersion. Mol Pharm. 2016 Jul 1 doi: 10.1021/acs.molpharmaceut.6b00391. X-1
4872 Chen Y, Wang S, Wang S, . Initial Drug Dissolution from Amorphous Solid Dispersions Controlled by Polymer Dissolution and Drug-Polymer Interaction. Pharm Res. 2016 Jun 9 doi: 10.1007/s11095-016-1969-2. X-1
4873 Chen YW, Bundy AC, Cordier R, . A cross-cultural exploration of the everyday social participation of individuals with autism spectrum disorders in Australia and Taiwan: An experience sampling study. Autism. 2016 Apr 27 doi: 10.1177/1362361316636756. X-1
4874 Chen Z, Trapp BD. Microglia and neuroprotection. J Neurochem. 2016 Jan;136 Suppl 1:10–7. doi: 10.1111/jnc.13062. X-125693054
4875 Cheng C, Lau SK, Doering LC. Astrocyte-secreted thrombospondin-1 modulates synapse and spine defects in the fragile X mouse model. Mol Brain. 2016;9(1):74. doi: 10.1186/s13041-016-0256-9. X-127485117
4876 Chenxi L, Chen Y, Li Y, . Complexity analysis of brain activity in attention-deficit/hyperactivity disorder: A multiscale entropy analysis. Brain Research Bulletin. 2016;124:12–20. doi: http://dx.doi.org/10.1016/j.brainresbull.2016.03.007. X-126995277
4877 Cheuk S, Lashewicz B. How are they doing? Listening as fathers of children with autism spectrum disorder compare themselves to fathers of children who are typically developing. Autism. 2016;20(3):343–52. doi: http://dx.doi.org/10.1177/1362361315584464. X-125976158
4878 Chezan L, Drasgow E, Legg J, . Effects of conditional discrimination training and choice opportunities on manding for two young children with Autism Spectrum Disorder and language delays. Journal of Developmental and Physical Disabilities. 2016;28(4):557–79. doi: http://dx.doi.org/10.1007/s10882-016-9493-1. X-3, X-4
4879 Chezan LC, Drasgow E, Martin CA, . Negatively-Reinforced Mands: An Examination of Resurgence to Existing Mands in Two Children With Autism and Language Delays. Behav Modif. 2016 May 9 doi: 10.1177/0145445516648664. X-1, X-3, X-4
4880 Chi DL, Momany ET, Mancl LA, . Dental homes for children with autism: A longitudinal analysis of Iowa Medicaid’s I-Smile Program. American Journal of Preventive Medicine. 2016;50(5):609–15. doi: http://dx.doi.org/10.1016/j.amepre.2015.08.022. X-126514624
4881 Chien HY, Gau SS, Isaac Tseng WY. Deficient visuospatial working memory functions and neural correlates of the default-mode network in adolescents with autism spectrum disorder. Autism Res. 2016 Feb 1 doi: 10.1002/aur.1607. X-1
4882 Chiocchetti AG, Haslinger D, Stein JL, . Transcriptomic signatures of neuronal differentiation and their association with risk genes for autism spectrum and related neuropsychiatric disorders. Transl Psychiatry. 2016;6(8):e864. doi: 10.1038/tp.2016.119. X-127483382
4883 Chiu MM, Roberts CA. Improved analyses of single cases: Dynamic multilevel analysis. Dev Neurorehabil. 2016 Feb 10:1–13. doi: 10.3109/17518423.2015.1119904. X-1
4884 Choi CH, Schoenfeld BP, Bell AJ, . Multiple Drug Treatments That Increase cAMP Signaling Restore Long-Term Memory and Aberrant Signaling in Fragile X Syndrome Models. Front Behav Neurosci. 2016;10:136. doi: 10.3389/fnbeh.2016.00136. X-127445731
4885 Choi GB, Yim YS, Wong H, . The maternal interleukin-17a pathway in mice promotes autism-like phenotypes in offspring. Science. 2016 Feb 26;351(6276):933–9. doi: 10.1126/science.aad0314. X-126822608
4886 Cholemkery H, Medda J, Lempp T, . Classifying autism spectrum disorders by ADI-R: Subtypes or severity gradient? Journal of Autism and Developmental Disorders. 2016;46(7):2327–39. doi: http://dx.doi.org/10.1007/s10803-016-2760-2. X-126956715
4887 Chong WH, Kua SM. Parenting Self-Efficacy Beliefs in Parents of Children With Autism: Perspectives From Singapore. Am J Orthopsychiatry. 2016 Apr 14 doi: 10.1037/ort0000169. X-1, X-3, X-4
4888 Choque Olsson N, Rautio D, Asztalos J, . Social skills group training in high-functioning autism: A qualitative responder study. Autism. 2016 Feb 24 doi: 10.1177/1362361315621885. X-1
4889 Christensen DL, Baio J, Van Naarden Braun K, . Prevalence and Characteristics of Autism Spectrum Disorder Among Children Aged 8 Years--Autism and Developmental Disabilities Monitoring Network, 11 Sites, United States, 2012. MMWR Surveill Summ. 2016 Apr 1;65(3):1–23. doi: 10.15585/mmwr.ss6503a1. X-1
4890 Christensen DL, Bilder DA, Zahorodny W, . Prevalence and characteristics of autism spectrum disorder among 4-year-old children in the autism and developmental disabilities monitoring network. Journal of Developmental and Behavioral Pediatrics. 2016;37(1):1–8. doi: http://dx.doi.org/10.1097/DBP.0000000000000235. X-126651088
4891 Christian EJ, Meltzer CL, Thede LL, . The Relationship Between Early Life Events, Parental Attachment, and Psychopathic Tendencies in Adolescent Detainees. Child Psychiatry Hum Dev. 2016 Mar 30 doi: 10.1007/s10578-016-0638-3. X-1, X-3
4892 Christiansz JA, Gray KM, Taffe J, . Autism spectrum disorder in the DSM-5: Diagnostic sensitivity and specificity in early childhood. Journal of Autism and Developmental Disorders. 2016;46(6):2054–63. doi: http://dx.doi.org/10.1007/s10803-016-2734-4. X-126861716
4893 Christoffersen GR, Schachtman TR. Electrophysiological CNS-processes related to associative learning in humans. Behav Brain Res. 2016 Jan 1;296:211–32. doi: 10.1016/j.bbr.2015.09.011. X-126367470
4894 Christou AI, Endo S, Wallis Y, . Variation in serotonin transporter linked polymorphic region (5-HTTLPR) short/long genotype modulates resting frontal electroencephalography asymmetries in children. Development and Psychopathology. 2016;28(1):239–50. doi: http://dx.doi.org/10.1017/S0954579415000413. X-125990287
4895 Chrobak AA, Soltys Z. Bergmann Glia, Long-Term Depression, and Autism Spectrum Disorder. Mol Neurobiol. 2016 Jan 26 doi: 10.1007/s12035-016-9719-3. X-1
4896 Chugani DC, Chugani HT, Wiznitzer M, . Efficacy of Low-Dose Buspirone for Restricted and Repetitive Behavior in Young Children with Autism Spectrum Disorder: A Randomized Trial. J Pediatr. 2016 Mar;170:45–53.e1–4. doi: 10.1016/j.jpeds.2015.11.033.26746121
4897 Chung J, Tchaconas A, Meryash D, . Treatment of attention-deficit/hyperactivity disorder in preschool-age children: Child and adolescent psychiatrists’ adherence to clinical practice guidelines. Journal of Child and Adolescent Psychopharmacology. 2016;26(4):335–43. doi: http://dx.doi.org/10.1089/cap.2015.0108. X-127105063
4898 Cianfaglione R, Meek A, Clarke A, . Direct observation of the behaviour of females with Rett syndrome. Journal of Developmental and Physical Disabilities. 2016;28(3):425–41. doi: http://dx.doi.org/10.1007/s10882-016-9478-0. X-127340365
4899 Ciernia AV, LaSalle J. The landscape of DNA methylation amid a perfect storm of autism aetiologies. Nat Rev Neurosci. 2016 Jul;17(7):411–23. doi: 10.1038/nrn.2016.41. X-127150399
4900 Cioffi CL, Guzzo PR. Inhibitors of Glycine Transporter-1: Potential Therapeutics for the Treatment of CNS Disorders. Curr Top Med Chem. 2016 Apr 5. X-1
4901 Clarke C, Hill V, Charman T. School based cognitive behavioural therapy targeting anxiety in children with autistic spectrum disorder: a quasi-experimental randomised controlled trail incorporating a mixed methods approach. J Autism Dev Disord. 2016 Apr 30 doi: 10.1007/s10803-016-2801-x. X-1, X-3
4902 Clince M, Connolly L, Nolan C. Comparing and Exploring the Sensory Processing Patterns of Higher Education Students With Attention Deficit Hyperactivity Disorder and Autism Spectrum Disorder. Am J Occup Ther. 2016 Mar–Apr;70(2):7002250010p1–9. doi: 10.5014/ajot.2016.016816. X-1, X-3
4903 Clipperton-Allen AE, Chen Y, Page DT. Autism-relevant behaviors are minimally impacted by conditional deletion of Pten in oxytocinergic neurons. Autism Res. 2016 May 25 doi: 10.1002/aur.1641. X-1
4904 Cohen IL, Liu X, Hudson M, . Using the PDD Behavior Inventory as a Level 2 Screener: A Classification and Regression Trees Analysis. J Autism Dev Disord. 2016 Jun 18 doi: 10.1007/s10803-016-2843-0. X-1
4905 Colbert AM, Webber J, Graham R. Factors that Influence Autism Knowledge in Hispanic Cultures: a Pilot Study. J Racial Ethn Health Disparities. 2016 Mar 11 doi: 10.1007/s40615-016-0213-4. X-1
4906 Conallen K, Reed P. A teaching procedure to help children with autistic spectrum disorder to label emotions. Research in Autism Spectrum Disorders. 2016;23:63–72. doi: http://dx.doi.org/10.1016/j.rasd.2015.11.006. X-1, X-3
4907 Congiu S, Fadda R, Doneddu G, . Impaired representational gaze following in children with autism spectrum disorder. Res Dev Disabil. 2016 Jun 24;57:11–7. doi: 10.1016/j.ridd.2016.06.008. X-127348855
4908 Connolly A, Fielding J, Papadopoulos N, . Factors Associated With Accidental Injuries in Children With ADHD-Combined Type: More Than a Motor Problem? J Atten Disord. 2016 Mar 14 doi: 10.1177/1087054716633857. X-1
4909 Connolly N, Anixt J, Manning P, . Maternal metabolic risk factors for autism spectrum disorder-An analysis of electronic medical records and linked birth data. Autism Res. 2016 Jan 29 doi: 10.1002/aur.1586. X-1
4910 Connolly SC, Millians M, Peterman R, . The clinical application of applied behavior analysis in a child with partial fetal alcohol syndrome: A case study. Clinical Case Studies. 2016;15(3):225–42. doi: http://dx.doi.org/10.1177/1534650116632298. X-1
4911 Conson M, Hamilton A, De Bellis F, . Body constraints on motor simulation in autism spectrum disorders. Journal of Autism and Developmental Disorders. 2016;46(3):1051–60. doi: http://dx.doi.org/10.1007/s10803-015-2652-x. X-126572656
4912 Constantino JN, Charman T. Diagnosis of autism spectrum disorder: reconciling the syndrome, its diverse origins, and variation in expression. Lancet Neurol. 2016 Mar;15(3):279–91. doi: 10.1016/s1474-4422(15)00151-9. X-126497771
4913 Contarino VE, Bulgheroni S, Annunziata S, . Widespread Focal Cortical Alterations in Autism Spectrum Disorder with Intellectual Disability Detected by Threshold-Free Cluster Enhancement. AJNR Am J Neuroradiol. 2016 Apr 21 doi: 10.3174/ajnr.A4779. X-1
4914 Contreras BP, Betz AM. Using lag schedules to strengthen the intraverbal repertoires of children with autism. Journal of Applied Behavior Analysis. 2016;49(1):3–16. doi: http://dx.doi.org/10.1002/jaba.271. X-1, X-3, X-426659709
4915 Coogle CG, Hanline MF. An exploratory study of family-centred help-giving practices in early intervention: Families of young children with autism spectrum disorder. Child & Family Social Work. 2016;21(2):249–60. doi: http://dx.doi.org/10.1111/cfs.12148. X-1
4916 Cope ZA, Powell SB, Young JW. Modeling neurodevelopmental cognitive deficits in tasks with cross-species translational validity. Genes Brain Behav. 2016 Jan;15(1):27–44. doi: 10.1111/gbb.12268. X-126667374
4917 Copf T. Impairments in dendrite morphogenesis as etiology for neurodevelopmental disorders and implications for therapeutic treatments. Neurosci Biobehav Rev. 2016 Apr 30 doi: 10.1016/j.neubiorev.2016.04.008. X-1
4918 Copping NA, Berg EL, Foley GM, . Touchscreen learning deficits and normal social approach behavior in the Shank3B model of Phelan-McDermid Syndrome and autism. Neuroscience. 2016 May 14 doi: 10.1016/j.neuroscience.2016.05.016. X-1
4919 Corbett BA, Blain SD, Ioannou S, . Changes in anxiety following a randomized control trial of a theatre-based intervention for youth with autism spectrum disorder. Autism. 2016 May 5 doi: 10.1177/1362361316643623. X-1
4920 Corbett BA, Muscatello RA, Blain SD. Impact of Sensory Sensitivity on Physiological Stress Response and Novel Peer Interaction in Children with and without Autism Spectrum Disorder. Front Neurosci. 2016;10:278. doi: 10.3389/fnins.2016.00278. X-127445653
4921 Corona LL, Fox SA, Christodulu KV, . Providing education on sexuality and relationships to adolescents with autism spectrum disorder and their parents. Sexuality and Disability. 2016;34(2):199–214. doi: http://dx.doi.org/10.1007/s11195-015-9424-6. X-1
4922 Cortelazzo A, De Felice C, Guerranti R, . Expression and oxidative modifications of plasma proteins in autism spectrum disorders: Interplay between inflammatory response and lipid peroxidation. Proteomics Clin Appl. 2016 Jun 1 doi: 10.1002/prca.201500076. X-1
4923 Coshway L, Broussard J, Acharya K, . Medical Therapy for Inappropriate Sexual Behaviors in a Teen With Autism Spectrum Disorder. Pediatrics. 2016 Apr;137(4)doi: 10.1542/peds.2015-4366. X-1, X-3, X-4
4924 Coskun S, Simsek S, Camkurt MA, . Association of polymorphisms in the vitamin D receptor gene and serum 25-hydroxyvitamin D levels in children with autism spectrum disorder. Gene. 2016 Aug 22;588(2):109–14. doi: 10.1016/j.gene.2016.05.004. X-127155524
4925 Costa V, Aigner S, Vukcevic M, . mTORC1 Inhibition Corrects Neurodevelopmental and Synaptic Alterations in a Human Stem Cell Model of Tuberous Sclerosis. Cell Rep. 2016 Apr 5;15(1):86–95. doi: 10.1016/j.celrep.2016.02.090. X-127052171
4926 Coster WJ, Kramer JM, Tian F, . Evaluating the appropriateness of a new computer-administered measure of adaptive function for children and youth with autism spectrum disorders. Autism. 2016;20(1):14–25. doi: http://dx.doi.org/10.1177/1362361314564473. X-125630376
4927 Courtemanche AB, Black WR. Everyday expressions of pain in children with and without autism spectrum disorder. Research in Autism Spectrum Disorders. 2016;26:65–70. doi: http://dx.doi.org/10.1016/j.rasd.2016.02.010. X-1
4928 Courtemanche AB, Black WR, Reese RM. The Relationship Between Pain, Self-Injury, and Other Problem Behaviors in Young Children With Autism and Other Developmental Disabilities. Am J Intellect Dev Disabil. 2016 May;121(3):194–203. doi: 10.1352/1944-7558-121.3.194. X-127119211
4929 Cowley B, Kirjanen S, Partanen J, . Epileptic Electroencephalography Profile Associates with Attention Problems in Children with Fragile X Syndrome: Review and Case Series. Front Hum Neurosci. 2016;10:353. doi: 10.3389/fnhum.2016.00353. X-127462212
4930 Craciun EC, Bjorklund G, Tinkov AA, . Evaluation of whole blood zinc and copper levels in children with autism spectrum disorder. Metab Brain Dis. 2016 Apr 8 doi: 10.1007/s11011-016-9823-0. X-1
4931 Craig F, Operto FF, De Giacomo A, . Parenting stress among parents of children with Neurodevelopmental Disorders. Psychiatry Res. 2016 Jun 1;242:121–9. doi: 10.1016/j.psychres.2016.05.016. X-127280521
4932 Crawford E, Aplin T, Rodger S. Human rights in occupational therapy education: A step towards a more occupationally just global society. Aust Occup Ther J. 2016 Aug 4 doi: 10.1111/1440-1630.12321. X-1
4933 Creer S, Enderby P, Judge S, . Prevalence of people who could benefit from augmentative and alternative communication (AAC) in the UK: determining the need. Int J Lang Commun Disord. 2016 Apr 26 doi: 10.1111/1460-6984.12235. X-1
4934 Crespi BJ. Autism As a Disorder of High Intelligence. Front Neurosci. 2016;10:300. doi: 10.3389/fnins.2016.00300. X-127445671
4935 Cribb SJ, Olaithe M, Di Lorenzo R, . Embedded Figures Test Performance in the Broader Autism Phenotype: A Meta-analysis. J Autism Dev Disord. 2016 Jun 16 doi: 10.1007/s10803-016-2832-3. X-1, X-2
4936 Crone RM, Mehta SS. Parent training on generalized use of behavior analytic strategies for decreasing the problem behavior of children with autism spectrum disorder: A data-based case study. Education & Treatment of Children. 2016;39(1):64–94. X-1, X-3
4937 Crossman MK, Kazdin AE. Additional Evidence is Needed to Recommend Acquiring a Dog to Families of Children with Autism Spectrum Disorder: A Response to Wright and Colleagues. J Autism Dev Disord. 2016 Jan;46(1):332–5. doi: 10.1007/s10803-015-2542-2. X-126231204
4938 Cruchet S, Lucero Y, Cornejo V. Truths, Myths and Needs of Special Diets: Attention-Deficit/Hyperactivity Disorder, Autism, Non-Celiac Gluten Sensitivity, and Vegetarianism. Ann Nutr Metab. 2016;68 Suppl 1:43–50. doi: 10.1159/000445393. X-127356007
4939 Crutcher E, Ali M, Harrison J, . Assessment of Cognitive Outcome Measures in Teenagers with 15q13.3 Microdeletion Syndrome. J Autism Dev Disord. 2016 Apr;46(4):1455–63. doi: 10.1007/s10803-015-2694-0. X-1, X-3, X-426754479
4940 Cubells JF, Schroeder JP, Barrie ES, . Human Bacterial Artificial Chromosome (BAC) Transgenesis Fully Rescues Noradrenergic Function in Dopamine beta-Hydroxylase Knockout Mice. PLoS One. 2016;11(5):e0154864. doi: 10.1371/journal.pone.0154864. X-127148966
4941 Cui T, Wang PP, Liu S, . P300 amplitude and latency in autism spectrum disorder: a meta-analysis. Eur Child Adolesc Psychiatry. 2016 Jun 14 doi: 10.1007/s00787-016-0880-z. X-1
4942 Cummings JR, Lynch FL, Rust KC, . Health services utilization among children with and without autism spectrum disorders. Journal of Autism and Developmental Disorders. 2016;46(3):910–20. doi: http://dx.doi.org/10.1007/s10803-015-2634-z. X-126547921
4943 Cupertino RB, Kappel DB, Bandeira CE, . SNARE complex in developmental psychiatry: neurotransmitter exocytosis and beyond. J Neural Transm (Vienna). 2016 Feb 8 doi: 10.1007/s00702-016-1514-9. X-1
4944 Curiel ESL, Sainato DM, Goldstein H. Matrix training of receptive language skills with a toddler with autism spectrum disorder: A case study. Education & Treatment of Children. 2016;39(1):95–109. X-1, X-3, X-4
4945 Curran EA, Cryan JF, Kenny LC, . Obstetrical mode of delivery and childhood behavior and psychological development in a British cohort. Journal of Autism and Developmental Disorders. 2016;46(2):603–14. doi: http://dx.doi.org/10.1007/s10803-015-2616-1. X-126412364
4946 Curtin C, Must A, Phillips S, . The healthy weight research network: a research agenda to promote healthy weight among youth with autism spectrum disorder and other developmental disabilities. Pediatr Obes. 2016 Feb 24 doi: 10.1111/ijpo.12109. X-1
4947 Cuzzocrea F, Murdaca AM, Costa S, . Parental stress, coping strategies and social support in families of children with a disability. Child Care in Practice. 2016;22(1):3–19. doi: http://dx.doi.org/10.1080/13575279.2015.1064357. X-1
4948 Cwik JC, Sartory G, Nuyken M, . Posterior and prefrontal contributions to the development posttraumatic stress disorder symptom severity: an fMRI study of symptom provocation in acute stress disorder. Eur Arch Psychiatry Clin Neurosci. 2016 Jul 25 doi: 10.1007/s00406-016-0713-6. X-1
4949 Cyranoski D. Monkeys genetically modified to show autism symptoms. Nature. 2016 Jan 28;529(7587):449. doi: 10.1038/529449a. X-126819024
4950 Dababnah S, Parish SL. Incredible Years program tailored to parents of preschoolers with autism: Pilot results. Research on Social Work Practice. 2016;26(4):372–85. doi: http://dx.doi.org/10.1177/1049731514558004. X-3
4951 D’Agati D, Chang AD, Wachtel LE, . Treatment of Severe Self-Injurious Behavior in Autism Spectrum Disorder by Neuromodulation. J ect. 2016 Jul 16 doi: 10.1097/yct.0000000000000346. X-1, X-2
4952 Dajani DR, Uddin LQ. Local brain connectivity across development in autism spectrum disorder: A cross-sectional investigation. Autism Res. 2016 Jan;9(1):43–54. doi: 10.1002/aur.1494. X-126058882
4953 Dajani DR, Uddin LQ. Local brain connectivity across development in autism spectrum disorder: A cross-sectional investigation. Autism Research. 2016;9(1):43–54. doi: http://dx.doi.org/10.1002/aur.1494. X-126058882
4954 Dallai R, Mercati D, Mashimo Y, . The fine structure of the rectal pads of Zorotypus caudelli Karny (Zoraptera, Insecta). Arthropod Struct Dev. 2016 Jun 28 doi: 10.1016/j.asd.2016.06.004. X-1
4955 Dallerac G, Rouach N. Astrocytes as new targets to improve cognitive functions. Prog Neurobiol. 2016 Mar 8 doi: 10.1016/j.pneurobio.2016.01.003. X-1
4956 Dalton C. Interaction Design in the Built Environment: Designing for the ‘Universal User’. Stud Health Technol Inform. 2016;229:314–23. X-127534322
4957 Danforth AL, Struble CM, Yazar-Klosinski B, . MDMA-assisted therapy: A new treatment model for social anxiety in autistic adults. Prog Neuropsychopharmacol Biol Psychiatry. 2016 Jan 4;64:237–49. doi: 10.1016/j.pnpbp.2015.03.011. X-125818246
4958 D’Angelo D, Lebon S, Chen Q, . Defining the Effect of the 16p11.2 Duplication on Cognition, Behavior, and Medical Comorbidities. JAMA Psychiatry. 2016 Jan;73(1):20–30. doi: 10.1001/jamapsychiatry.2015.2123. X-126629640
4959 Danielsson H, Henry L, Messer D, . Developmental delays in phonological recoding among children and adolescents with Down syndrome and Williams syndrome. Research in Developmental Disabilities. 2016;55:64–76. doi: http://dx.doi.org/10.1016/j.ridd.2016.03.012. X-127043367
4960 Darbro BW, Singh R, Zimmerman MB, . Autism Linked to Increased Oncogene Mutations but Decreased Cancer Rate. PLoS One. 2016;11(3):e0149041. doi: 10.1371/journal.pone.0149041. X-126934580
4961 Darville H, Poulet A, Rodet-Amsellem F, . Human Pluripotent Stem Cell-derived Cortical Neurons for High Throughput Medication Screening in Autism: A Proof of Concept Study in SHANK3 Haploinsufficiency Syndrome. EBioMedicine. 2016 May 27 doi: 10.1016/j.ebiom.2016.05.032. X-1
4962 Das S, Kumar P, Bhardwaj V, . Anesthetic management of Amplatzer atrial septal defect closure device embolization to right ventricular outflow tract. Saudi J Anaesth. 2016 Jul–Sep;10(3):335–8. doi: 10.4103/1658-354x.174911. X-127375392
4963 Daurio NA, Tuttle SW, Worth AJ, . AMPK Activation and Metabolic Reprogramming by Tamoxifen through Estrogen Receptor-Independent Mechanisms Suggests New Uses for This Therapeutic Modality in Cancer Treatment. Cancer Res. 2016 Jun 1;76(11):3295–306. doi: 10.1158/0008-5472.can-15-2197. X-127020861
4964 Davids RC, Groen Y, Berg IJ, . Executive Functions in Older Adults With Autism Spectrum Disorder: Objective Performance and Subjective Complaints. J Autism Dev Disord. 2016 Jun 8 doi: 10.1007/s10803-016-2831-4. X-1
4965 Davidson JM, Wong CT, Rai-Bhogal R, . Prostaglandin E2 elevates calcium in differentiated neuroectodermal stem cells. Mol Cell Neurosci. 2016 Apr 10;74:71–7. doi: 10.1016/j.mcn.2016.03.010. X-127074429
4966 Davis J, McKone E, Zirnsak M, . Social and attention-to-detail subclusters of autistic traits differentially predict looking at eyes and face identity recognition ability. Br J Psychol. 2016 Mar 14 doi: 10.1111/bjop.12188. X-1
4967 Daviss WB, Barnett E, Neubacher K, . Use of antipsychotic medications for nonpsychotic children: Risks and implications for mental health services. Psychiatric Services. 2016;67(3):339–41. doi: http://dx.doi.org/10.1176/appi.ps.201500272. X-126725298
4968 De Felice A, Greco A, Calamandrei G, . Prenatal exposure to the organophosphate insecticide chlorpyrifos enhances brain oxidative stress and prostaglandin E2 synthesis in a mouse model of idiopathic autism. J Neuroinflammation. 2016;13(1):149. doi: 10.1186/s12974-016-0617-4. X-127301868
4969 de Jong S, Newhouse SJ, Patel H, . Immune signatures and disorder-specific patterns in a cross-disorder gene expression analysis. Br J Psychiatry. 2016 May 5 doi: 10.1192/bjp.bp.115.175471. X-1
4970 De la Garza Ramos R, Passias PG, Schwab F, . Incidence, Risk Factors, and Mortality of Reintubation in Adult Spinal Deformity Surgery. Clin Spine Surg.. 2016 Jun 27 doi: 10.1097/bsd.0000000000000404. X-1
4971 De la Garza-Ramos R, Jain A, Kebaish KM, . Inpatient morbidity and mortality after adult spinal deformity surgery in teaching versus nonteaching hospitals. J Neurosurg Spine. 2016 Jul;25(1):15–20. doi: 10.3171/2015.11.spine151021. X-126943252
4972 De La Torre L, Cogley K, Calisto J, . Primary sigmoidectomy and appendicostomy for chronic idiopathic constipation. Pediatr Surg Int.. 2016 Jul 2 doi: 10.1007/s00383-016-3913-2. X-1
4973 de la Torre-Ubieta L, Won H, Stein JL, . Advancing the understanding of autism disease mechanisms through genetics. Nat Med. 2016 Apr;22(4):345–61. doi: 10.1038/nm.4071. X-127050589
4974 de Schipper E, Mahdi S, de Vries P, . Functioning and disability in autism spectrum disorder: A worldwide survey of experts. Autism Res. 2016 Jan 8 doi: 10.1002/aur.1592. X-1, X-2
4975 Dean OM, Gray KM, Villagonzalo KA, . A randomised, double blind, placebo-controlled trial of a fixed dose of N-acetyl cysteine in children with autistic disorder. Aust N Z J Psychiatry. 2016 Jun 17 doi: 10.1177/0004867416652735.
4976 Decety J, Bartal IB, Uzefovsky F, . Empathy as a driver of prosocial behaviour: highly conserved neurobehavioural mechanisms across species. Philos Trans R Soc Lond B Biol Sci. 2016 Jan 19;371(1686):20150077. doi: 10.1098/rstb.2015.0077. X-126644596
4977 Deckers A, Muris P, Roelofs J, . A Group-Administered social Skills Training for 8- to 12- Year-Old, high-Functioning Children With Autism Spectrum Disorders: An Evaluation of its Effectiveness in a Naturalistic Outpatient Treatment Setting. J Autism Dev Disord. 2016 Aug 13 doi: 10.1007/s10803-016-2887-1. X-1
4978 Degenhardt F, Niklowitz P, Szymczak S, . Genome-wide association study of serum coenzyme Q10 levels identifies susceptibility loci linked to neuronal diseases. Hum Mol Genet. 2016 May 5 doi: 10.1093/hmg/ddw134. X-1
4979 deJong NA, Williams CS, Thomas KC. Parent-reported health consequences and relationship to expenditures in children with ADHD. Maternal and Child Health Journal. 2016;20(4):915–24. doi: http://dx.doi.org/10.1007/s10995-015-1880-1. X-126754346
4980 Dekker AP, Salar O, Karuppiah SV, . Anxiety and depression predict poor outcomes in arthroscopic subacromial decompression. J Shoulder Elbow Surg. 2016 Jun;25(6):873–80. doi: 10.1016/j.jse.2016.01.031. X-127068379
4981 Dekker V, Nauta MH, Mulder EJ, . A Fresh Pair of Eyes: A Blind Observation Method for Evaluating Social Skills of Children with ASD in a Naturalistic Peer Situation in School. J Autism Dev Disord. 2016 Jun 11 doi: 10.1007/s10803-016-2829-y. X-1
4982 Del Casale A, Kotzalidis GD, Sacco M, . Effectiveness of switching from oral ziprasidone to risperidone in a patient with comorbid autistic disorder, profound intellectual disability, Gilbert syndrome, and exacerbation of psychosis. Psychiatr Danub. 2016 Mar;28(1):91–4. X-1, X-326938829
4983 Dell’Osso L, Abelli M, Carpita B, . Historical evolution of the concept of anorexia nervosa and relationships with orthorexia nervosa, autism, and obsessive-compulsive spectrum. Neuropsychiatr Dis Treat. 2016;12:1651–60. doi: 10.2147/ndt.s108912. X-127462158
4984 Demirci A, Kartal M. The prevalence of developmental delay among children aged 3–60 months in Izmir, Turkey. Child: Care, Health and Development. 2016;42(2):213–9. doi: http://dx.doi.org/10.1111/cch.12289. X-1
4985 Demopoulos C, Hopkins J, Lewine JD. Relations Between Nonverbal and Verbal Social Cognitive Skills and Complex Social Behavior in Children and Adolescents with Autism. J Abnorm Child Psychol. 2016 Jul;44(5):913–21. doi: 10.1007/s10802-015-0082-z. X-126386582
4986 Dempsey J, Dempsey AG, Guffey D, . Brief report: Further examination of self-injurious behaviors in children and adolescents with autism spectrum disorders. Journal of Autism and Developmental Disorders. 2016;46(5):1872–9. doi: http://dx.doi.org/10.1007/s10803-016-2704-x. X-126781113
4987 Demurie E, Roeyers H, Wiersema JR, . No evidence for inhibitory deficits or altered reward processing in ADHD: Data from a new integrated monetary incentive delay go/no-go task. Journal of Attention Disorders. 2016;20(4):353–67. doi: http://dx.doi.org/10.1177/1087054712473179. X-123382578
4988 Derguy C, M’Bailara K, Michel G, . The need for an ecological approach to parental stress in autism spectrum disorders: The combined role of individual and environmental factors. Journal of Autism and Developmental Disorders. 2016;46(6):1895–905. doi: http://dx.doi.org/10.1007/s10803-016-2719-3. X-126858031
4989 DeRosa NM, Roane HS, Bishop JR, . The combined effects of noncontingent reinforcement and punishment on the reduction of rumination. J Appl Behav Anal. 2016 Mar 21 doi: 10.1002/jaba.304. X-1
4990 Desai A, Sequeira JM, Quadros EV. The metabolic basis for developmental disorders due to defective folate transport. Biochimie. 2016 Jul;126:31–42. doi: 10.1016/j.biochi.2016.02.012. X-126924398
4991 Deutsch SI, Burket JA, Benson AD, . The 15q13.3 deletion syndrome: Deficient alpha7-containing nicotinic acetylcholine receptor-mediated neurotransmission in the pathogenesis of neurodevelopmental disorders. Prog Neuropsychopharmacol Biol Psychiatry. 2016 Jan 4;64:109–17. doi: 10.1016/j.pnpbp.2015.08.001. X-126257138
4992 Devescovi R, Monasta L, Mancini A, . Early diagnosis and Early Start Denver Model intervention in autism spectrum disorders delivered in an Italian Public Health System service. Neuropsychiatr Dis Treat. 2016;12:1379–84. doi: 10.2147/ndt.s106850. X-327366069
4993 Dewinter J, Van Parys H, Vermeiren R, . Adolescent boys with an autism spectrum disorder and their experience of sexuality: An interpretative phenomenological analysis. Autism. 2016 Mar 7 doi: 10.1177/1362361315627134. X-1
4994 Dewinter J, Vermeiren R, Vanwesenbeeck I, . Adolescent boys with autism spectrum disorder growing up: follow-up of self-reported sexual experience. Eur Child Adolesc Psychiatry. 2016 Jan 20 doi: 10.1007/s00787-016-0816-7. X-1
4995 Di Biasi S, Trimarco B, D’Ardia C, . Psychological adjustment, social responsiveness and parental distress in an Italian sample of siblings of children with high-functioning autism spectrum disorder. Journal of Child and Family Studies. 2016;25(3):883–90. doi: http://dx.doi.org/10.1007/s10826-015-0256-x. X-1
4996 Di Palma S, Tonacci A, Narzisi A, . Monitoring of autonomic response to sociocognitive tasks during treatment in children with Autism Spectrum Disorders by wearable technologies: A feasibility study. Comput Biol Med.. 2016 Apr 5 doi: 10.1016/j.compbiomed.2016.04.001. X-1
4997 Di Rezze B, Rosenbaum P, Zwaigenbaum L, . Developing a classification system of social communication functioning of preschool children with autism spectrum disorder. Dev Med Child Neurol.. 2016 May 17 doi: 10.1111/dmcn.13152. X-1
4998 Dias APBH, de Vasconcelos MM, de Souza Maia Filho H, . Assessment of pragmatic language in verbal and nonverbal autistic children. Revista de Logopedia, Foniatría y Audiología. 2016;36(1):15–22. doi: http://dx.doi.org/10.1016/j.rlfa.2015.02.001. X-1
4999 Diaz Heijtz R. Fetal, neonatal, and infant microbiome: Perturbations and subsequent effects on brain development and behavior. Semin Fetal Neonatal Med. 2016 May 30 doi: 10.1016/j.siny.2016.04.012. X-1
5000 Dick IE, Joshi-Mukherjee R, Yang W, . Arrhythmogenesis in Timothy Syndrome is associated with defects in Ca(2+)-dependent inactivation. Nat Commun. 2016;7:10370. doi: 10.1038/ncomms10370. X-126822303
5001 Dickerson AS, Rahbar MH, Bakian AV, . Autism spectrum disorder prevalence and associations with air concentrations of lead, mercury, and arsenic. Environ Monit Assess. 2016 Jul;188(7):407. doi: 10.1007/s10661-016-5405-1. X-127301968
5002 Dickinson A, Jones M, Milne E. Measuring neural excitation and inhibition in autism: different approaches, different findings and different interpretations. Brain Res. 2016 Jul 12 doi: 10.1016/j.brainres.2016.07.011. X-1
5003 Dickinson K, Place M. The Impact of a Computer-Based Activity Program on the Social Functioning of Children with Autistic Spectrum Disorder. Games Health J. 2016 Jun;5(3):209–15. doi: 10.1089/g4h.2015.0063. X-127104364
5004 Dickson PE, Cairns J, Goldowitz D, . Cerebellar contribution to higher and lower order rule learning and cognitive flexibility in mice. Neuroscience. 2016 Mar 21 doi: 10.1016/j.neuroscience.2016.03.040. X-1
5005 Dickstein DP, Axelson D, Weissman AB, . Cognitive flexibility and performance in children and adolescents with threshold and sub-threshold bipolar disorder. Eur Child Adolesc Psychiatry. 2016 Jun;25(6):625–38. doi: 10.1007/s00787-015-0769-2. X-126438382
5006 DiCriscio AS, Miller SJ, Hanna EK, . Brief Report: Cognitive Control of Social and Nonsocial Visual Attention in Autism. J Autism Dev Disord. 2016 May 13 doi: 10.1007/s10803-016-2804-7. X-1
5007 Didehbani N, Allen T, Kandalaft M, . Virtual Reality Social Cognition Training for children with high functioning autism. Computers in Human Behavior. 2016;62:703–11. doi: http://dx.doi.org/10.1016/j.chb.2016.04.033. X-3
5008 Didriksen M, Fejgin K, Nilsson SR, . Persistent gating deficit and increased sensitivity to NMDA receptor antagonism after puberty in a new mouse model of the human 22q11.2 microdeletion syndrome: a study in male mice. J Psychiatry Neurosci. 2016 Jul 7;41(5):150381. doi: 10.1503/jpn.150381. X-1
5009 Didry P, Didry E. Psychological care. Rev Infirm. 2016 Jan(217):47–8. doi: 10.1016/j.revinf.2015.10.027. X-1
5010 Diebo BG, Gammal I, Ha Y, . Role of Ethnicity in Alignment Compensation: Propensity Matched Analysis of Differential Compensatory Mechanism Recruitment Patterns for Sagittal Malalignment in 288 ASD Patients from Japan, Korea and United States. Spine (Phila Pa 1976). 2016 Jun 17 doi: 10.1097/brs.0000000000001744. X-1
5011 Diener ML, Wright CA, Dunn L, . A creative 3D design programme: Building on interests and social engagement for students with autism spectrum disorder (ASD). International Journal of Disability, Development and Education. 2016;63(2):181–200. doi: http://dx.doi.org/10.1080/1034912X.2015.1053436. X-1, X-3
5012 DiGuiseppi CG, Daniels JL, Fallin DM, . Demographic profile of families and children in the Study to Explore Early Development (SEED): Case-control study of autism spectrum disorder. Disability and Health Journal. 2016;9(3):544–51. doi: http://dx.doi.org/10.1016/j.dhjo.2016.01.005. x-126917104
5013 Dima I, Deshpande A. Right heart dilatation: a rare vascular cause. Heart. 2016 Mar 21 doi: 10.1136/heartjnl-2015-309172. X-1
5014 Dimitrova N, Özçalışkan Ş, Adamson LB. Parents’ translations of child gesture facilitate word learning in children with autism, Down syndrome and typical development. Journal of Autism and Developmental Disorders. 2016;46(1):221–31. doi: http://dx.doi.org/10.1007/s10803-015-2566-7. X-126362150
5015 Ding Y, Ruan DK, He Q, . Imaging Evaluation and Relative Significance in Cases of Cervical Disc Allografting: Radiographic Character Following Total Disc Transplantation. Clin Spine Surg. 2016 May 11 doi: 10.1097/BSD.0b013e318290fc41. X-1
5016 DiStefano C, Gulsrud A, Huberty S, . Identification of a distinct developmental and behavioral profile in children with Dup15q syndrome. J Neurodev Disord. 2016;8:19. doi: 10.1186/s11689-016-9152-y. X-127158270
5017 DiStefano C, Shih W, Kaiser A, . Communication growth in minimally verbal children with ASD: The importance of interaction. Autism Res. 2016 Jan 29 doi: 10.1002/aur.1594. X-1, X-3
5018 Dittrich S, Sigler M, Priessmann H. Late complete atrioventricular block after closure of an atrial septal defect with a gore septal occluder (GSO). Catheter Cardiovasc Interv. 2016 Apr;87(5):945–50. doi: 10.1002/ccd.26154. X-126354228
5019 Dixon MR, Stanley CR, Belisle J, . The test-retest and interrater reliability of the Promoting the Emergence of Advanced Knowledge-Direct Training assessment for use with individuals with autism and related disabilities. Behavior Analysis: Research and Practice. 2016;16(1):34–40. doi: http://dx.doi.org/10.1037/bar0000027. X-1
5020 Doenyas C. The Social Living Complex: A New, All Day, Yearlong Intervention Model for Individuals with Autism Spectrum Disorder and Their Parents. J Autism Dev Disord. 2016 Jun 22 doi: 10.1007/s10803-016-2846-x. X-1, X-2, X-3
5021 Doernberg E, Hollander E. Neurodevelopmental Disorders (ASD and ADHD): DSM-5, ICD-10, and ICD-11. CNS Spectr. 2016 Jul 1:1–5. doi: 10.1017/s1092852916000262. X-1
5022 Dolan BK, Van Hecke AV, Carson AM, . Brief Report: Assessment of Intervention Effects on In Vivo Peer Interactions in Adolescents with Autism Spectrum Disorder (ASD). J Autism Dev Disord. 2016 Jun;46(6):2251–9. doi: 10.1007/s10803-016-2738-0. X-126886470
5023 Dolev S, Sher-Censor E, Baransi N, . Resolution of the child’s ASD diagnosis among Arab–Israeli mothers: Associations with maternal sensitivity and wellbeing. Research in Autism Spectrum Disorders. 2016;21:73–83. doi: http://dx.doi.org/10.1016/j.rasd.2015.09.004. X-1
5024 Doll CA, Broadie K. Neuron class-specific requirements for Fragile X Mental Retardation Protein in critical period development of calcium signaling in learning and memory circuitry. Neurobiol Dis. 2016 May;89:76–87. doi: 10.1016/j.nbd.2016.02.006. X-126851502
5025 Donaldson CK, Stauder JE, Donkers FC. Increased Sensory Processing Atypicalities in Parents of Multiplex ASD Families Versus Typically Developing and Simplex ASD Families. J Autism Dev Disord. 2016 Aug 18 doi: 10.1007/s10803-016-2888-0. X-1
5026 Dong F, Jiang J, McSweeney C, . Deletion of CTNNB1 in inhibitory circuitry contributes to autism-associated behavioral defects. Hum Mol Genet. 2016 Apr 30 doi: 10.1093/hmg/ddw131. X-1
5027 Dong T, He J, Wang S, . Inability to activate Rac1-dependent forgetting contributes to behavioral inflexibility in mutants of multiple autism-risk genes. Proc Natl Acad Sci U S A. 2016 Jun 22 doi: 10.1073/pnas.1602152113. X-1
5028 Doumas M, McKenna R, Murphy B. Postural control deficits in autism spectrum disorder: The role of sensory integration. Journal of Autism and Developmental Disorders. 2016 2016-02-25;46(3):853–61. doi: 10.1176/appi.books.9780890423349. 10.1016/j.rasd.2013.09.016. http://dx.doi.org/10.1007/s10803-015-2621-4; 2015-46759-001. X-126446773
5029 Dow D, Guthrie W, Stronach ST, . Psychometric analysis of the Systematic Observation of Red Flags for autism spectrum disorder in toddlers. Autism. 2016 Apr 30 doi: 10.1177/1362361316636760. X-1
5030 Downs J, Torode I, Ellaway C, . Family satisfaction following spinal fusion in Rett syndrome. Developmental Neurorehabilitation. 2016;19(1):31–7. doi: http://dx.doi.org/10.3109/17518423.2014.898107. X-124724550
5031 Drasgow E, Martin CA, Chezan LC, . Mand training: An examination of response-class structure in three children with autism and severe language delays. Behavior Modification. 2016;40(3):347–76. doi: http://dx.doi.org/10.1177/0145445515613582. X-1, X-3, X-426541166
5032 Du F, Nguyen MV, Karten A,. Acute and crucial requirement for MeCP2 function upon transition from early to late adult stages of brain maturation. Hum Mol Genet. 2016 Feb 16 doi: 10.1093/hmg/ddw038. X-1
5033 Dua K, McAvoy WC, Klaus SA, . Hospitalist Co-management of Pediatric Orthopaedic Surgical Patients at a Community Hospital. Md Med. 2016;17(1):34–6. X-127443131
5034 Dube WV, Farber RS, Mueller MR, . Stimulus Overselectivity in Autism, Down Syndrome, and Typical Development. Am J Intellect Dev Disabil. 2016 May;121(3):219–35. doi: 10.1352/1944-7558-121.3.219. X-127119213
5035 Dubiel A, Kulesza RJ, Jr.. Prenatal valproic acid exposure disrupts tonotopic c-Fos expression in the rat brainstem. Neuroscience. 2016 Jun 2;324:511–23. doi: 10.1016/j.neuroscience.2016.01.030. X-127094734
5036 DuBois D, Ameis SH, Lai MC, . Interoception in Autism Spectrum Disorder: A review. Int J Dev Neurosci. 2016 Jun 3;52:104–11. doi: 10.1016/j.ijdevneu.2016.05.001. X-127269967
5037 Duda M, Daniels J, Wall DP. Clinical evaluation of a Novel and Mobile Autism Risk Assessment. Journal of Autism and Developmental Disorders. 2016;46(6):1953–61. doi: http://dx.doi.org/10.1007/s10803-016-2718-4. X-126873142
5038 Dungan JA, Stepanovic M, Young L. Theory of mind for processing unexpected events across contexts. Soc Cogn Affect Neurosci. 2016 Mar 12 doi: 10.1093/scan/nsw032. X-1, X-2
5039 Dunkel-Jackson SM, Dixon MR, Szekely S. Self-control as generalized operant behavior by adults with autism spectrum disorder. J Appl Behav Anal. 2016 May 14 doi: 10.1002/jaba.315. X-1
5040 Dunlop JA, Lamsdell JC. Segmentation and tagmosis in Chelicerata. Arthropod Struct Dev. 2016 Jun 21 doi: 10.1016/j.asd.2016.05.002. X-1
5041 Durante AS, Wieselberg MB, Roque N, . Assessment of hearing threshold in adults with hearing loss using an automated system of cortical auditory evoked potential detection. Braz J Otorhinolaryngol. 2016 Apr 29 doi: 10.1016/j.bjorl.2016.02.016. X-1
5042 Duringer J, Fombonne E, Craig M. No Association between Mycotoxin Exposure and Autism: A Pilot Case-Control Study in School-Aged Children. Toxins (Basel). 2016;8(7)doi: 10.3390/toxins8070224. X-1
5043 Durkin MS, Benedict RE, Christensen D, . Prevalence of Cerebral Palsy among 8-Year-Old Children in 2010 and Preliminary Evidence of Trends in Its Relationship to Low Birthweight. Paediatr Perinat Epidemiol. 2016 May 23 doi: 10.1111/ppe.12299. X-1
5044 Durrleman S, Burnel M, Thommen E, . The language cognition interface in ASD: Complement sentences and false belief reasoning. Research in Autism Spectrum Disorders. 2016;21:109–20. doi: http://dx.doi.org/10.1016/j.rasd.2015.10.003. X-1
5045 Dutta MM, Sanyal N. A comparative study of emotional characteristics of children with and without ADHD by “Draw a Man test”. Journal of Projective Psychology & Mental Health. 2016;23(1):27–33. X-1
5046 Duvekot J, Ende J, Constantino JN, . Symptoms of autism spectrum disorder and anxiety: Shared familial transmission and cross-assortative mating. Journal of Child Psychology and Psychiatry. 2016;57(6):759–69. doi: http://dx.doi.org/10.1111/jcpp.12508. X-126714925
5047 Duyzend MH, Nuttle X, Coe BP, . Maternal Modifiers and Parent-of-Origin Bias of the Autism-Associated 16p11.2 CNV. Am J Hum Genet. 2016 Jan 7;98(1):45–57. doi: 10.1016/j.ajhg.2015.11.017. X-126749307
5048 Dynia JM, Brock ME, Logan JAR, . Comparing children with ASD and their peers’ growth in print knowledge. Journal of Autism and Developmental Disorders. 2016;46(7):2490–500. doi: http://dx.doi.org/10.1007/s10803-016-2790-9. X-127113339
5049 Eapen V. Early identification of autism spectrum disorder: Do we need a paradigm shift? Aust N Z J Psychiatry. 2016 Jun 9 doi: 10.1177/0004867416652733. X-1
5050 Earle JF. An Introduction to the Psychopharmacology of Children and Adolescents With Autism Spectrum Disorder. J Child Adolesc Psychiatr Nurs. 2016 Jun 9 doi: 10.1111/jcap.12144. X-1
5051 Eberhardt M, Nadig A. Reduced sensitivity to context in language comprehension: A characteristic of Autism Spectrum Disorders or of poor structural language ability? Res Dev Disabil. 2016 Feb 18 doi: 10.1016/j.ridd.2016.01.017. X-1
5052 Ecker C. The neuroanatomy of autism spectrum disorder: An overview of structural neuroimaging findings and their translatability to the clinical setting. Autism. 2016 Mar 14 doi: 10.1177/1362361315627136. X-1, X-2
5053 Eddy CM. The junction between self and other? Temporo-parietal dysfunction in neuropsychiatry. Neuropsychologia. 2016 Jul 25;89:465–77. doi: 10.1016/j.neuropsychologia.2016.07.030. X-127457686
5054 Edgar JC, Fisk CLIV, Liu S, . Translating adult electrophysiology findings to younger patient populations: Difficulty measuring 40-Hz auditory steady-state responses in typically developing children and children with autism spectrum disorder. Developmental Neuroscience. 2016;38(1):1–14. doi: http://dx.doi.org/10.1159/000441943. X-126730806
5055 Edmiston EK, Blain SD, Corbett BA. Salivary cortisol and behavioral response to social evaluative threat in adolescents with autism spectrum disorder. Autism Res. 2016 Jul 15 doi: 10.1002/aur.1660. X-1
5056 Edmiston EK, Jones RM, Corbett BA. Physiological Response to Social Evaluative Threat in Adolescents with Autism Spectrum Disorder. J Autism Dev Disord. 2016 Jun 18 doi: 10.1007/s10803-016-2842-1. X-1
5057 Edmunds SR, Ibanez LV, Warren Z, . Longitudinal prediction of language emergence in infants at high and low risk for autism spectrum disorder. Dev Psychopathol. 2016 Apr 6:1–11. doi: 10.1017/s0954579416000146. X-1
5058 Edwards A, Brebner C, McCormack PF, . “More than blowing bubbles”: What parents want from therapists working with children with autism spectrum disorder. Int J Speech Lang Pathol. 2016 Apr 4:1–13. doi: 10.3109/17549507.2015.1112835. X-1
5059 Egger JI, Zwanenburg RJ, van Ravenswaaij-Arts CM, . Neuropsychological phenotype and psychopathology in seven adult patients with Phelan-McDermid syndrome: implications for treatment strategy. Genes Brain Behav. 2016 Apr;15(4):395–404. doi: 10.1111/gbb.12285. X-126824576
5060 Egilson ST, Jakobsdottir G, Olafsson K, . Community participation and environment of children with and without autism spectrum disorder: parent perspectives. Scand J Occup Ther. 2016 Jun 22:1–10. doi: 10.1080/11038128.2016.1198419. X-1
5061 Egilson ST, Olafsdottir LB, Leosdottir T, . Quality of life of high-functioning children and youth with autism spectrum disorder and typically developing peers: Self- and proxy-reports. Autism. 2016 Apr 5 doi: 10.1177/1362361316630881. X-1
5062 Einarsson IÞ, Jóhannsson E, Daly D, . Physical activity during school and after school among youth with and without intellectual disability. Research in Developmental Disabilities. 2016;56:60–70. doi: http://dx.doi.org/10.1016/j.ridd.2016.05.016. X-127262443
5063 Ekas NV, Ghilain C, Pruitt M, . The role of family cohesion in the psychological adjustment of non-Hispanic White and Hispanic mothers of children with autism spectrum disorder. Research in Autism Spectrum Disorders. 2016;21:10–24. doi: http://dx.doi.org/10.1016/j.rasd.2015.09.002. X-1
5064 Ekberg TL, Falck-Ytter T, Bölte S, . Reduced prospective motor control in 10-month-olds at risk for autism spectrum disorder. Clinical Psychological Science. 2016;4(1):129–35. doi: http://dx.doi.org/10.1177/2167702615576697. X-1
5065 Elagoz Yuksel M, Yuceturk B, Karatas OF, . The Altered Promoter Methylation Of Oxytocin Receptor Gene In Autism. J Neurogenet. 2016 Jun 16:1–15. doi: 10.1080/01677063.2016.1202951. X-1
5066 El-Ansary A. Data of multiple regressions analysis between selected biomarkers related to glutamate excitotoxicity and oxidative stress in Saudi autistic patients. Data Brief. 2016 Jun;7:111–6. doi: 10.1016/j.dib.2016.02.025. X-126933667
5067 Elberling H, Linneberg A, Rask CU, . Psychiatric disorders in Danish children aged 5–7 years: A general population study of prevalence and risk factors from the Copenhagen Child Cohort (CCC 2000). Nordic Journal of Psychiatry. 2016;70(2):146–55. doi: http://dx.doi.org/10.3109/08039488.2015.1070199. X-126509656
5068 Elder JH, Brasher S, Alexander B. Identifying the Barriers to Early Diagnosis and Treatment in Underserved Individuals with Autism Spectrum Disorders (ASD) and Their Families: A Qualitative Study. Issues Ment Health Nurs. 2016 Jun;37(6):412–20. doi: 10.3109/01612840.2016.1153174. X-127070190
5069 Ella B, Ghorayeb I, Burbaud P, . Bruxism in Movement Disorders: A Comprehensive Review. J Prosthodont. 2016 Apr 14 doi: 10.1111/jopr.12479. X-1
5070 Elliott C, Dillenburger K. The effect of choice on motivation for young children on the autism spectrum during discrete trial teaching. Journal of Research in Special Educational Needs. 2016;16(3):187–98. doi: http://dx.doi.org/10.1111/1471-3802.12073. X-3, X-4
5071 Elrod MG, Nylund CM, Susi AL, . Prevalence of Diagnosed Sleep Disorders and Related Diagnostic and Surgical Procedures in Children with Autism Spectrum Disorders. J Dev Behav Pediatr. 2016 Jun;37(5):377–84. doi: 10.1097/dbp.0000000000000248. X-126982246
5072 Elton A, Di Martino A, Hazlett HC, . Neural connectivity evidence for a categorical-dimensional hybrid model of autism spectrum disorder. Biological Psychiatry. 2016;80(2):120–8. doi: http://dx.doi.org/10.1016/j.biopsych.2015.10.020. X-126707088
5073 Eluri Z, Andrade I, Trevino N, . Assessment and treatment of problem behavior maintained by mand compliance. J Appl Behav Anal. 2016 Jun;49(2):383–7. doi: 10.1002/jaba.296. X-1, X-426831251
5074 Elwin M, Schroder A, Ek L, . Development and pilot validation of a sensory reactivity scale for adults with high functioning autism spectrum conditions: Sensory Reactivity in Autism Spectrum (SR-AS). Nord J Psychiatry. 2016;70(2):103–10. doi: 10.3109/08039488.2015.1053984. X-126158770
5075 Ely E, Chen-Lim ML, Carpenter KM, II, . Pain assessment of children with autism spectrum disorders. Journal of Developmental and Behavioral Pediatrics. 2016;37(1):53–61. doi: http://dx.doi.org/10.1097/DBP.0000000000000240. X-126703326
5076 Emamalizadeh B, Jamshidi J, Movafagh A, . RIT2 Polymorphisms: Is There a Differential Association? Mol Neurobiol. 2016 Mar 3 doi: 10.1007/s12035-016-9815-4. X-1
5077 Emberti Gialloreti L, Benvenuto A, Battan B, . Can biological components predict short-term evolution in Autism Spectrum Disorders? A proof-of-concept study. Ital J Pediatr. 2016;42(1):70. doi: 10.1186/s13052-016-0281-4. X-127448796
5078 Emerson ND, Morrell HER, Neece C. Predictors of age of diagnosis for children with autism spectrum disorder: The role of a consistent source of medical care, race, and condition severity. Journal of Autism and Developmental Disorders. 2016;46(1):127–38. doi: http://dx.doi.org/10.1007/s10803-015-2555-x. X-126280401
5079 Engevik LI, Næss K-AB, Hagtvet BE. Cognitive stimulation of pupils with Down syndrome: A study of inferential talk during book-sharing. Research in Developmental Disabilities. 2016;55:287–300. doi: http://dx.doi.org/10.1016/j.ridd.2016.05.004. X-127214682
5080 Engle K, Rada R. Knowledge-guided mutation in classification rules for autism treatment efficacy. Health Informatics J. 2016 Feb 11 doi: 10.1177/1460458215627187. X-1
5081 Ercan ES, Suren S, Bacanlı A, . Decreasing ADHD phenotypic heterogeneity: Searching for neurobiological underpinnings of the restrictive inattentive phenotype. European Child & Adolescent Psychiatry. 2016;25(3):273–82. doi: http://dx.doi.org/10.1007/s00787-015-0731-3. X-126058607
5082 Ergaz Z, Weinstein-Fudim L, Ornoy A. Genetic and non-genetic animal models for autism spectrum disorders (ASD). Reprod Toxicol. 2016 Apr 30 doi: 10.1016/j.reprotox.2016.04.024. X-1
5083 Erickson CA, Wink LK, Baindu B, . Analysis of peripheral amyloid precursor protein in Angelman Syndrome. Am J Med Genet A. 2016 Jun 21 doi: 10.1002/ajmg.a.37811. X-1
5084 Eriksson JM, Lundstrom S, Lichtenstein P, . Effect of co-twin gender on neurodevelopmental symptoms: a twin register study. Mol Autism. 2016;7:8. doi: 10.1186/s13229-016-0074-z. X-126793297
5085 Erskine HE, Baxter AJ, Patton G, . The global coverage of prevalence data for mental disorders in children and adolescents. Epidemiol Psychiatr Sci. 2016 Jan 20:1–8. doi: 10.1017/s2045796015001158. X-1
5086 Erturk O, Korkmaz B, Alev G, . Startle and blink reflex in high functioning autism. Neurophysiol Clin. 2016 Mar 17 doi: 10.1016/j.neucli.2016.02.001. X-1
5087 Estabillo JA, Matson JL, Jiang X. The association between familial ASD diagnosis, autism symptomatology and developmental functioning in young children. Eur Child Adolesc Psychiatry. 2016 Mar 16 doi: 10.1007/s00787-016-0838-1. X-1
5088 Estes ML, McAllister AK. IMMUNOLOGY. Maternal TH17 cells take a toll on baby’s brain. Science. 2016 Feb 26;351(6276):919–20. doi: 10.1126/science.aaf2850. X-126917755
5089 Estes ML, McAllister AK. Maternal immune activation: Implications for neuropsychiatric disorders. Science. 2016 Aug 19;353(6301):772–7. doi: 10.1126/science.aag3194. X-127540164
5090 Evrensel A, Ceylan ME. Fecal Microbiota Transplantation and Its Usage in Neuropsychiatric Disorders. Clin Psychopharmacol Neurosci. 2016 Aug 31;14(3):231–7. doi: 10.9758/cpn.2016.14.3.231. X-127489376
5091 Ewen JB, Lakshmanan BM, Pillai AS, . Decreased Modulation of EEG Oscillations in High-Functioning Autism during a Motor Control Task. Front Hum Neurosci. 2016;10:198. doi: 10.3389/fnhum.2016.00198. X-127199719
5092 Factor RS, Condy EE, Farley JP, . Brief Report: Insistence on Sameness, Anxiety, and Social Motivation in Children with Autism Spectrum Disorder. J Autism Dev Disord. 2016 Jul;46(7):2548–54. doi: 10.1007/s10803-016-2781-x. X-127040556
5093 Fairthorne J, Hammond G, Bourke J, . Maternal psychiatric disorder and the risk of autism spectrum disorder or intellectual disability in subsequent offspring. Journal of Autism and Developmental Disorders. 2016;46(2):523–33. doi: http://dx.doi.org/10.1007/s10803-015-2594-3. X-1, X-3, X-426373768
5094 Fairthorne JC, de Klerk NH, Leonard HM, . Mothers of Children with Autism have Different Rates of Cancer According to the Presence of Intellectual Disability in Their Child. J Autism Dev Disord. 2016 Sep;46(9):3106–14. doi: 10.1007/s10803-016-2847-9. X-127384537
5095 Faja S, Dawson G, Aylward E, . Early event-related potentials to emotional faces differ for adults with autism spectrum disorder and by serotonin transporter genotype. Clin Neurophysiol. 2016 Jun;127(6):2436–47. doi: 10.1016/j.clinph.2016.02.022. X-127178863
5096 Faja S, Dawson G, Sullivan K, . Executive function predicts the development of play skills for verbal preschoolers with autism spectrum disorders. Autism Res. 2016 Feb 18 doi: 10.1002/aur.1608. X-1
5097 Falahpour M, Thompson WK, Abbott AE, . Underconnected, but not broken? Dynamic functional connectivity MRI shows underconnectivity in autism is linked to increased intra-individual variability across time. Brain Connectivity. 2016;6(5):403–14. doi: http://dx.doi.org/10.1089/brain.2015.0389. X-126973154
5098 Falk A, Heine VM, Harwood AJ, . Modeling psychiatric disorders: from genomic findings to cellular phenotypes. Mol Psychiatry. 2016 May 31 doi: 10.1038/mp.2016.89. X-1
5099 Faller P, Hunt J, van Hooydonk E, . Application of Data-Driven Decision Making Using Ayres Sensory Integration((R)) With a Child With Autism. Am J Occup Ther. 2016 Jan–Feb;70(1):7001220020p1–9. doi: 10.5014/ajot.2016.016881. X-1
5100 Fallon LM, Collier-Meek MA, Sanetti LMH, . Implementation planning to promote parents’ treatment integrity of behavioral interventions for children with autism. Journal of Educational & Psychological Consultation. 2016;26(1):87–109. doi: http://dx.doi.org/10.1080/10474412.2015.1039124. X-1, X-3, X-4
5101 Farahmand D, Saehle T, Eide PK, . A double-blind randomized trial on the clinical effect of different shunt valve settings in idiopathic normal pressure hydrocephalus. J Neurosurg. 2016 Feb;124(2):359–67. doi: 10.3171/2015.1.jns141301. X-126315004
5102 Farber RS, Dube WV, Dickson CA. A sorting-to-matching method to teach compound matching to sample. Journal of Applied Behavior Analysis. 2016;49(2):294–307. doi: http://dx.doi.org/10.1002/jaba.290. X-1, X-3, X-426843215
5103 Farhat F, Hsairi I, Baati H, . The effect of a motor skills training program in the improvement of practiced and non-practiced tasks performance in children with developmental coordination disorder (DCD). Human Movement Science. 2016;46:10–22. doi: http://dx.doi.org/10.1016/j.humov.2015.12.001. X-126703915
5104 Farmer C, Golden C, Thurm A. Concurrent validity of the differential ability scales, second edition with the Mullen Scales of Early Learning in young children with and without neurodevelopmental disorders. Child Neuropsychology. 2016;22(5):556–69. doi: http://dx.doi.org/10.1080/09297049.2015.1020775. X-125833070
5105 Farmer M, Echenne B, Bentourkia Mh. Study of clinical characteristics in young subjects with developmental coordination disorder. Brain & Development. 2016;38(6):538–47. doi: http://dx.doi.org/10.1016/j.braindev.2015.12.010. X-126763621
5106 Farrant K, Uddin LQ. Atypical developmental of dorsal and ventral attention networks in autism. Developmental Science. 2016;19(4):550–63. doi: http://dx.doi.org/10.1111/desc.12359. X-126613549
5107 Faught GG, Conners FA, Barber AB, . Addressing phonological memory in language therapy with clients who have Down syndrome: Perspectives of speech-language pathologists. Int J Lang Commun Disord. 2016 May 5 doi: 10.1111/1460-6984.12241. X-1
5108 Fausey CM, Jayaraman S, Smith LB. From faces to hands: Changing visual input in the first two years. Cognition. 2016;152:101–7. doi: http://dx.doi.org/10.1016/j.cognition.2016.03.005. X-127043744
5109 Feinberg E, Abufhele M, Sandler J, . Reducing Disparities in Timely Autism Diagnosis Through Family Navigation: Results From a Randomized Pilot Trial. Psychiatr Serv. 2016 May 2:appips201500162. doi: 10.1176/appi.ps.201500162. X-1
5110 Feng J, Shan L, Du L, . Clinical improvement following vitamin D3 supplementation in Autism Spectrum Disorder. Nutr Neurosci. 2016 Jan 18 doi: 10.1080/1028415x.2015.1123847. X-3
5111 Ferguson BJ, Marler S, Altstein LL, . Psychophysiological Associations with Gastrointestinal Symptomatology in Autism Spectrum Disorder. Autism Res. 2016 Jun 20 doi: 10.1002/aur.1646. X-1
5112 Ferguson BJ, Marler S, Altstein LL, . Associations between cytokines, endocrine stress response, and gastrointestinal symptoms in autism spectrum disorder. Brain Behav Immun. 2016 May 12 doi: 10.1016/j.bbi.2016.05.009. X-1
5113 Fernandez-Alcantara M, Garcia-Caro MP, Perez-Marfil MN, . Feelings of loss and grief in parents of children diagnosed with autism spectrum disorder (ASD). Res Dev Disabil. 2016 May 24;55:312–21. doi: 10.1016/j.ridd.2016.05.007. X-127235768
5114 Ferrero E, Liabaud B, Challier V, . Role of pelvic translation and lower-extremity compensation to maintain gravity line position in spinal deformity. J Neurosurg Spine. 2016 Mar;24(3):436–46. doi: 10.3171/2015.5.spine14989. X-126565764
5115 Ferron L. Fragile X mental retardation protein controls ion channel expression and activity. J Physiol. 2016 Feb 10 doi: 10.1113/jp270675. X-1
5116 Field SS. Nutrition and Autism: Intervention Compared with Identification. Adv Nutr. 2016 Mar;7(2):420–1. doi: 10.3945/an.115.011700. X-2
5117 Field T. Massage therapy research review. Complement Ther Clin Pract. 2016 Aug;24:19–31. doi: 10.1016/j.ctcp.2016.04.005. X-127502797
5118 Filice F, Vorckel KJ, Sungur AO, . Reduction in parvalbumin expression not loss of the parvalbumin-expressing GABA interneuron subpopulation in genetic parvalbumin and shank mouse models of autism. Mol Brain. 2016;9:10. doi: 10.1186/s13041-016-0192-8. X-126819149
5119 Findon J, Cadman T, Stewart CS, . Screening for co-occurring conditions in adults with autism spectrum disorder using the strengths and difficulties questionnaire: A pilot study. Autism Res. 2016 Mar 28 doi: 10.1002/aur.1625. X-1
5120 Finnegan E, Mazin AL. Strategies for increasing reading comprehension skills in students with Autism Spectrum Disorder: A review of the literature. Education & Treatment of Children. 2016;39(2):187–220. doi: http://dx.doi.org/10.1353/etc.2016.0007. X-1, X-2
5121 Fisch GS, Falk RE, Carey JC, . Deletion 2q37 syndrome: Cognitive-behavioral trajectories and autistic features related to breakpoint and deletion size. Am J Med Genet A. 2016 Jun 9 doi: 10.1002/ajmg.a.37782. X-1
5122 Fisher MH, Lense MD, Dykens EM. Longitudinal trajectories of intellectual and adaptive functioning in adolescents and adults with Williams syndrome. J Intellect Disabil Res. 2016 Jun 8 doi: 10.1111/jir.12303. X-1
5123 Fitzgerald J, Gallagher L, McGrath J. Widespread Disrupted White Matter Microstructure in Autism Spectrum Disorders. J Autism Dev Disord. 2016 May 20 doi: 10.1007/s10803-016-2803-8. X-1
5124 Fitzpatrick SE, Srivorakiat L, Wink LK, . Aggression in autism spectrum disorder: presentation and treatment options. Neuropsychiatr Dis Treat. 2016;12:1525–38. doi: 10.2147/ndt.s84585. X-1, X-2, X-327382295
5125 Fletcher FE, Foster-Owens MD, Conduit R, . The development trajectory of parent-report and objective sleep profiles in autism spectrum disorder: Associations with anxiety and bedtime routines. Autism. 2016 Jun 26 doi: 10.1177/1362361316653365. X-1
5126 Fletcher-Watson S, Apicella F, Auyeung B, . Attitudes of the autism community to early autism research. Autism. 2016 Mar 14 doi: 10.1177/1362361315626577. X-1
5127 Flore G, Cioffi S, Bilio M, . Cortical Development Requires Mesodermal Expression of Tbx1, a Gene Haploinsufficient in 22q11.2 Deletion Syndrome. Cereb Cortex. 2016 Mar 21 doi: 10.1093/cercor/bhw076. X-1
5128 Fluegge K. Does MeCP2 deficiency in autism confer protection against later development of Alzheimer’s disease? A reply to Oberman and Pascual-Leone (2014). Med Hypotheses. 2016 Jul;92:18–20. doi: 10.1016/j.mehy.2016.04.020. X-127241247
5129 Fluegge K. Maternal infection during pregnancy, risk of offspring autism, and the role of bacterial denitrification. Brain Behav Immun. 2016 Jun 24 doi: 10.1016/j.bbi.2016.06.013. X-1
5130 Fluegge K. The role of air pollution exposures in mediating nutritional biochemical profiles in autism: A reply to Jory (2015). Nutrition. 2016 Mar 6 doi: 10.1016/j.nut.2016.02.017. X-1
5131 Fluegge K. Methyl B12 and Autism Spectrum Disorders: Any Clues to Etiology? J Child Adolesc Psychopharmacol. 2016 Apr 22 doi: 10.1089/cap.2016.0038. X-1
5132 Fluegge K. Do Toxic Synergies of Underlying Etiologies Predispose the Positive Association Between Traumatic Brain Injury and ADHD? J Atten Disord. 2016 Mar 8 doi: 10.1177/1087054716633858. X-1, X-2
5133 Fluegge K. Environmental factors in the development of autism spectrum disorders: A reply to Sealey, et al. (2016). Environ Int.. 2016 Feb 26 doi: 10.1016/j.envint.2016.02.024. X-1, X-2, X-3
5134 Fluegge K. Does the Clinical Benefit of Ketamine Treatment Offer Any Clues to Autism Spectrum Disorder Etiology? J Clin Psychiatry. 2016 Jul;77(7):e903. doi: 10.4088/JCP.16lr10663. X-127464326
5135 Fluegge K. A reply to ‘Metabolic effects of sapropterin treatment in autism spectrum disorder: a preliminary study’. Transl Psychiatry. 2016;6:e793. doi: 10.1038/tp.2016.24. X-1, X-227115124
5136 Flynn SD, Lo Y-y. Teacher implementation of trial-based functional analysis and differential reinforcement of alternative behavior for students with challenging behavior. Journal of Behavioral Education. 2016;25(1):1–31. doi: http://dx.doi.org/10.1007/s10864-015-9231-2. X-1, X-3, X-4
5137 Fogarty MJ, Kanjhan R, Bellingham MC, . Glycinergic Neurotransmission: A Potent Regulator of Embryonic Motor Neuron Dendritic Morphology and Synaptic Plasticity. J Neurosci. 2016 Jan 6;36(1):80–7. doi: 10.1523/jneurosci.1576-15.2016. X-126740651
5138 Fombonne E. Prenatal Antidepressant Use and Risk of Autism Spectrum Disorders in the Children. JAMA Pediatr. 2016 May 31 doi: 10.1001/jamapediatrics.2016.0745. X-1
5139 Fombonne E, Marcin C, Manero AC, . Prevalence of autism spectrum disorders in Guanajuato, Mexico: The Leon survey. Journal of Autism and Developmental Disorders. 2016;46(5):1669–85. doi: http://dx.doi.org/10.1007/s10803-016-2696-6. X-126797939
5140 Ford TC, Crewther DP. A Comprehensive Review of the (1)H-MRS Metabolite Spectrum in Autism Spectrum Disorder. Front Mol Neurosci. 2016;9:14. doi: 10.3389/fnmol.2016.00014. X-127013964
5141 Forgeot d’Arc B, Ramus F, Lefebvre A, . Atypical social judgment and sensitivity to perceptual cues in autism spectrum disorders. Journal of Autism and Developmental Disorders. 2016;46(5):1574–81. doi: http://dx.doi.org/10.1007/s10803-014-2208-5. X-125149177
5142 Forgeot d’Arc B, Delorme R, Zalla T, . Gaze direction detection in autism spectrum disorder. Autism. 2016 Apr 30 doi: 10.1177/1362361316630880. X-1
5143 Forsingdal A, Fejgin K, Nielsen V, . 15q13.3 homozygous knockout mouse model display epilepsy-, autism- and schizophrenia-related phenotypes. Transl Psychiatry. 2016;6(7):e860. doi: 10.1038/tp.2016.125. X-127459725
5144 Forslund T, Brocki KC, Bohlin G, . The heterogeneity of attention-deficit/hyperactivity disorder symptoms and conduct problems: Cognitive inhibition, emotion regulation, emotionality, and disorganized attachment. British Journal of Developmental Psychology. 2016;34(3):371–87. doi: http://dx.doi.org/10.1111/bjdp.12136. X-126895773
5145 Foss-Feig JH, McGugin RW, Gauthier I, . A functional neuroimaging study of fusiform response to restricted interests in children and adolescents with autism spectrum disorder. Journal of Neurodevelopmental Disorders. 2016;8 doi: http://dx.doi.org/10.1186/s11689-016-9149-6. X-126981159
5146 Foster NEV, Ouimet T, Tryfon A, . Effects of age and attention on auditory global–local processing in children with autism spectrum disorder. Journal of Autism and Developmental Disorders. 2016;46(4):1415–28. doi: http://dx.doi.org/10.1007/s10803-015-2684-2. X-126724923
5147 Fountain MD, Aten E, Cho MT, . The phenotypic spectrum of Schaaf-Yang syndrome: 18 new affected individuals from 14 families. Genet Med. 2016 May 19 doi: 10.1038/gim.2016.53. X-1
5148 Franzetti E, Casartelli M, D’Antona P, . Midgut epithelium in molting silkworm: A fine balance among cell growth, differentiation, and survival. Arthropod Struct Dev. 2016 Jul;45(4):368–79. doi: 10.1016/j.asd.2016.06.002. X-127349418
5149 Frazier TW, Klingemier EW, Beukemann M, . Development of an objective autism risk index using remote eye tracking. Journal of the American Academy of Child & Adolescent Psychiatry. 2016;55(4):301–9. doi: http://dx.doi.org/10.1016/j.jaac.2016.01.011. X-127015721
5150 Freeman NC, Gray KM, Taffe JR, . A cross-syndrome evaluation of a new attention rating scale: The Scale of Attention in intellectual Disability. Res Dev Disabil. 2016 Jun 24;57:18–28. doi: 10.1016/j.ridd.2016.06.005. X-127348856
5151 Freeman SM, Samineni S, Allen PC, . Plasma and CSF oxytocin levels after intranasal and intravenous oxytocin in awake macaques. Psychoneuroendocrinology. 2016 Apr;66:185–94. doi: 10.1016/j.psyneuen.2016.01.014. X-126826355
5152 Freitag CM, Jensen K, Elsuni L, . Group-based cognitive behavioural psychotherapy for children and adolescents with ASD: The randomized, multicentre, controlled SOSTA – net trial. Journal of Child Psychology and Psychiatry. 2016;57(5):596–605. doi: http://dx.doi.org/10.1111/jcpp.12509. X-1, X-426715086
5153 Frey AJ, Feldman DR, Trefely S, . LC-quadrupole/Orbitrap high-resolution mass spectrometry enables stable isotope-resolved simultaneous quantification and (1)(3)C-isotopic labeling of acyl-coenzyme A thioesters. Anal Bioanal Chem. 2016 May;408(13):3651–8. doi: 10.1007/s00216-016-9448-5. X-126968563
5154 Fried R, Joshi G, Bhide P, . A study of the neuropsychological correlates in adults with high functioning autism spectrum disorders. Acta Neuropsychiatr. 2016 Apr 4:1–10. doi: 10.1017/neu.2016.12. X-1
5155 Frye RE, Rossignol DA. Identification and Treatment of Pathophysiological Comorbidities of Autism Spectrum Disorder to Achieve Optimal Outcomes. Clin Med Insights Pediatr. 2016;10:43–56. doi: 10.4137/CMPed.S38337. X-127330338
5156 Fujioka T, Inohara K, Okamoto Y, . Gazefinder as a clinical supplementary tool for discriminating between autism spectrum disorder and typical development in male adolescents and adults. Mol Autism. 2016;7:19. doi: 10.1186/s13229-016-0083-y. X-127011784
5157 Fujiwara T, Sanada M, Kofuji T, . Unusual social behavior in HPC-1/syntaxin1A knockout mice is caused by disruption of the oxytocinergic neural system. J Neurochem. 2016 Jul;138(1):117–23. doi: 10.1111/jnc.13634. X-127059771
5158 Fukumura K. Development of audience design in children with and without ASD. Developmental Psychology. 2016;52(1):71–87. doi: http://dx.doi.org/10.1037/dev0000064. X-126524381
5159 Furey H. Aristotle and Autism: Reconsidering a Radical Shift to Virtue Ethics in Engineering. Sci Eng Ethics. 2016 Jun 29 doi: 10.1007/s11948-016-9787-9. X-1
5160 Gabis LV, Gruber N, Berkenstadt M, . Fragile X Premutation Carrier Epidemiology and Symptomatology in Israel-Results from a Tertiary Child Developmental Center. Cerebellum. 2016 Jun 17 doi: 10.1007/s12311-016-0804-y. X-1
5161 Gabriele S, Sacco R, Altieri L, . Slow intestinal transit contributes to elevate urinary p-cresol level in Italian autistic children. Autism Research. 2016;9(7):752–9. doi: http://dx.doi.org/10.1002/aur.1571. X-126437875
5162 Gadow KD, Perlman G, Ramdhany L, . Clinical correlates of co-occurring psychiatric and autism spectrum disorder (ASD) symptom-induced impairment in children with ASD. Journal of Abnormal Child Psychology. 2016;44(1):129–39. doi: http://dx.doi.org/10.1007/s10802-015-9979-9. X-125640910
5163 Galling B, Roldan A, Nielsen RE, . Type 2 Diabetes Mellitus in Youth Exposed to Antipsychotics: A Systematic Review and Meta-analysis. JAMA Psychiatry. 2016 Mar;73(3):247–59. doi: 10.1001/jamapsychiatry.2015.2923. X-126792761
5164 Gandal MJ, Geschwind DH. The Genetics-Driven Revival in Neuropsychiatric Drug Development. Biol Psychiatry. 2016 Apr 15;79(8):628–30. doi: 10.1016/j.biopsych.2016.02.024. X-126997117
5165 Gangi DN, Messinger DS, Martin ER, . Dopaminergic variants in siblings at high risk for autism: Associations with initiating joint attention. Autism Res. 2016 Mar 15 doi: 10.1002/aur.1623. X-1
5166 Gao Y, Wang F, Eisinger BE, . Integrative Single-Cell Transcriptomics Reveals Molecular Networks Defining Neuronal Maturation During Postnatal Neurogenesis. Cereb Cortex. 2016 Mar 17 doi: 10.1093/cercor/bhw040. X-1
5167 Garcia D, Dukes C, Brady MP, . Using modeling and rehearsal to teach fire safety to children with autism. J Appl Behav Anal. 2016 Jun 30 doi: 10.1002/jaba.331. X-1, X-3
5168 Garcia-Lopez C, Sarria E, Pozo P. Parental Self-Efficacy and Positive Contributions Regarding Autism Spectrum Condition: An Actor-Partner Interdependence Model. J Autism Dev Disord. 2016 Jul;46(7):2385–98. doi: 10.1007/s10803-016-2771-z. X-127007725
5169 García-López C, Sarriá E, Pozo P. Parental self-efficacy and positive contributions regarding autism spectrum condition: An actor–partner interdependence model. Journal of Autism and Developmental Disorders. 2016;46(7):2385–98. doi: http://dx.doi.org/10.1007/s10803-016-2771-z. X-127007725
5170 Garcia-Villamisar D, Dattilo J, Muela C. Effects of therapeutic recreation on adults with ASD and ID: a preliminary randomized control trial. J Intellect Disabil Res. 2016 Jul 28 doi: 10.1111/jir.12320. X-1
5171 Garg P, Lillystone D, Dossetor D, . A Pilot Study for Understanding the Perceptions of Australian General Practitioners Regarding Psychopharmacology for Children With Autism Spectrum Disorders. J Prim Care Community Health. 2016 Apr 20 doi: 10.1177/2150131916644030. X-1
5172 Garman HD, Spaulding CJ, Webb SJ, . Wanting it Too Much: An Inverse Relation Between Social Motivation and Facial Emotion Recognition in Autism Spectrum Disorder. Child Psychiatry Hum Dev. 2016 Jan 7 doi: 10.1007/s10578-015-0620-5. X-1
5173 Garon N, Zwaigenbaum L, Bryson S, . Temperament and its association with autism symptoms in a high-risk population. Journal of Abnormal Child Psychology. 2016;44(4):757–69. doi: http://dx.doi.org/10.1007/s10802-015-0064-1. X-126315156
5174 Gart N, Zamora I, Williams ME. Parallel models of assessment: Infant mental health and therapeutic assessment models intersect through early childhood case studies. Infant Mental Health Journal. 2016;37(4):452–65. doi: http://dx.doi.org/10.1002/imhj.21573. X-127333488
5175 Gassowska M, Baranowska-Bosiacka I, Moczydlowska J, . Perinatal exposure to lead (Pb) promotes Tau phosphorylation in the rat brain in a GSK-3beta and CDK5 dependent manner: Relevance to neurological disorders. Toxicology. 2016 Mar 10;347–349:17–28. doi: 10.1016/j.tox.2016.03.002. X-1
5176 Gaudi S, Guffanti G, Fallon J, . Epigenetic mechanisms and associated brain circuits in the regulation of positive emotions: A role for Transposable Elements. J Comp Neurol. 2016 May 25 doi: 10.1002/cne.24046. X-1
5177 Geary N, Bachler T, Whiting L, . RYGB progressively increases avidity for a low-energy, artificially sweetened diet in female rats. Appetite. 2016 Mar 1;98:133–41. doi: 10.1016/j.appet.2015.11.029. X-126707654
5178 Gee BM, Peterson TW. Changes in Caregiver Knowledge and Perceived Competency Following Group Education about Sensory Processing Disturbances: An Exploratory Study. Occup Ther Int. 2016 Jul 4 doi: 10.1002/oti.1435. X-1
5179 Gellen B, Volgyi K, Gyorffy BA, . Proteomic investigation of the prefrontal cortex in the rat clomipramine model of depression. J Proteomics. 2016 Jun 28 doi: 10.1016/j.jprot.2016.06.027. X-1
5180 Geretsegger M, Holck U, Bieleninik L, . Feasibility of a Trial on Improvisational Music Therapy for Children with Autism Spectrum Disorder. J Music Ther. 2016 Summer;53(2):93–120. doi: 10.1093/jmt/thv038. X-127084832
5181 Getz KD, Anderka MT, Werler MM, . Maternal Pre-pregnancy Body Mass Index and Autism Spectrum Disorder among Offspring: A Population-Based Case-Control Study. Paediatr Perinat Epidemiol. 2016 May 30 doi: 10.1111/ppe.12306. X-1
5182 Getz SA, DeSpenza T, Jr., Li M, . Rapamycin prevents, but does not reverse, aberrant migration in Pten knockout neurons. Neurobiol Dis. 2016 Sep;93:12–20. doi: 10.1016/j.nbd.2016.03.010. X-126992888
5183 Gevarter C, O’Reilly MF, Kuhn M, . Increasing the vocalizations of individuals with autism during intervention with a speech-generating device. Journal of Applied Behavior Analysis. 2016;49(1):17–33. doi: http://dx.doi.org/10.1002/jaba.270. X-3, X-426640163
5184 Ghaleiha A, Alikhani R, Kazemi MR, . Minocycline as Adjunctive Treatment to Risperidone in Children with Autistic Disorder: A Randomized, Double-Blind Placebo-Controlled Trial. J Child Adolesc Psychopharmacol. 2016 Apr 29 doi: 10.1089/cap.2015.0175.
5185 Ghalichi F, Ghaemmaghami J, Malek A, . Effect of gluten free diet on gastrointestinal and behavioral indices for children with autism spectrum disorders: a randomized clinical trial. World J Pediatr. 2016 Jun 10 doi: 10.1007/s12519-016-0040-z.
5186 Ghilain CS, Parlade MV, McBee MT, . Validation of the Pictorial Infant Communication Scale for preschool-aged children with autism spectrum disorder. Autism. 2016 Apr 30 doi: 10.1177/1362361316636757. X-1
5187 Gialluisi A, Visconti A, Willcutt EG, . Investigating the effects of copy number variants on reading and language performance. Journal of Neurodevelopmental Disorders. 2016;8 doi: http://dx.doi.org/10.1186/s11689-016-9147-8. X-126981159
5188 Giannakopoulos A, Fryssira H, Tzetis M, . Central precocious puberty in a boy with 22q13 deletion syndrome and NOTCH-1 gene duplication. J Pediatr Endocrinol Metab. 2016 May 28 doi: 10.1515/jpem-2015-0484. X-1
5189 Giannopulu I, Montreynaud V, Watanabe T. Minimalistic toy robot to analyze a scenery of speaker–listener condition in autism. Cognitive Processing. 2016;17(2):195–203. doi: http://dx.doi.org/10.1007/s10339-016-0752-y. X-1, X-326872960
5190 Gidaya NB, Lee BK, Burstyn I, . In utero Exposure to beta-2-Adrenergic Receptor Agonist Drugs and Risk for Autism Spectrum Disorders. Pediatrics. 2016 Feb;137(2):e20151316. doi: 10.1542/peds.2015-1316. X-126738885
5191 Giles LL, Martini DR. Challenges and Promises of Pediatric Psychopharmacology. Acad Pediatr. 2016 Apr 5 doi: 10.1016/j.acap.2016.03.011. X-1
5192 Ginevra MC, Nota L, Stokes MA. The differential effects of autism and down’s syndrome on sexual behavior. Autism Research. 2016;9(1):131–40. doi: http://dx.doi.org/10.1002/aur.1504. X-126055556
5193 Gnanasekaran S, Choueiri R, Neumeyer A, . Impact of employee benefits on families with children with autism spectrum disorders. Autism. 2016;20(5):616–22. doi: http://dx.doi.org/10.1177/1362361315598891. X-126341992
5194 Gogliotti RG, Senter RK, Rook JM, . mGlu5 positive allosteric modulation normalizes synaptic plasticity defects and motor phenotypes in a mouse model of Rett syndrome. Hum Mol Genet. 2016 Mar 2 doi: 10.1093/hmg/ddw074. X-1
5195 Gogou M, Spilioti M, Tramma D, . Succinic Semialdehyde Dehydrogenase Deficiency Presenting as Autism Spectrum Disorder. Indian J Pediatr. 2016 Jan 25 doi: 10.1007/s12098-015-2003-0. X-1
5196 Goin-Kochel RP. Musings on the puzzle piece. Autism. 2016 Feb;20(2):250. doi: 10.1177/1362361315602135. X-126395235
5197 Goldberg MC, Allman MJ, Hagopian LP, . Examining the reinforcing value of stimuli within social and non-social contexts in children with and without high-functioning autism. Autism. 2016 Jul 1 doi: 10.1177/1362361316655035. X-1
5198 Goldfarb C, Genore L, Hunt C, . Hyperbaric oxygen therapy for the treatment of children and youth with Autism Spectrum disorders: An evidence-based systematic review. Research in Autism Spectrum Disorders. 2016;29–30:1–7. doi: http://dx.doi.org/10.1016/j.rasd.2016.05.004. X-2
5199 Goldin RL, Matson JL. Premature birth as a risk factor for autism spectrum disorder. Developmental Neurorehabilitation. 2016;19(3):203–6. X-125992682
5200 Goldschmidt J. What Happened to Paul? Manifestation of Abnormal Pain Response for Individuals With Autism Spectrum Disorder. Qual Health Res. 2016 Apr 26 doi: 10.1177/1049732316644415. X-1
5201 Golub MS, Hogrefe CE, Bulleri AM. Peer social interaction is facilitated in juvenile rhesus monkeys treated with fluoxetine. Neuropharmacology. 2016 Jun;105:553–60. doi: 10.1016/j.neuropharm.2016.02.025. X-126905291
5202 Gomez-Perez MM, Calero MD, Mata S, . Discrepancies between direct and indirect measures of interpersonal and neurocognitive skills in autism spectrum disorder children. J Clin Exp Neuropsychol. 2016 Oct;38(8):875–86. doi: 10.1080/13803395.2016.1170106. X-127192042
5203 Gonthier C, Longuepee L, Bouvard M. Sensory Processing in Low-Functioning Adults with Autism Spectrum Disorder: Distinct Sensory Profiles and Their Relationships with Behavioral Dysfunction. J Autism Dev Disord. 2016 Jun 30 doi: 10.1007/s10803-016-2850-1. X-1
5204 Gordon-Lipkin E, Foster J, Peacock G. Whittling Down the Wait Time: Exploring Models to Minimize the Delay from Initial Concern to Diagnosis and Treatment of Autism Spectrum Disorder. Pediatr Clin North Am. 2016 Oct;63(5):851–9. doi: 10.1016/j.pcl.2016.06.007. X-127565363
5205 Gorman K, Olson L, Hill AP, . Uh and um in children with autism spectrum disorders or language impairment. Autism Res. 2016 Jan 22 doi: 10.1002/aur.1578. X-1
5206 Goulardins JB, Rigoli D, Piek JP, . The relationship between motor skills, ADHD symptoms, and childhood body weight. Research in Developmental Disabilities. 2016;55:279–86. doi: http://dx.doi.org/10.1016/j.ridd.2016.05.005. X-127214681
5207 Grabb MC, Gobburu JV. Challenges in developing drugs for pediatric CNS disorders: A focus on psychopharmacology. Prog Neurobiol. 2016 May 20 doi: 10.1016/j.pneurobio.2016.05.003. X-1
5208 Grainger C, Williams DM, Lind SE. Recognition memory and source memory in autism spectrum disorder: A study of the intention superiority and enactment effects. Autism. 2016 Jun 22 doi: 10.1177/1362361316653364. X-1
5209 Grainger C, Williams DM, Lind SE. Metacognitive monitoring and control processes in children with autism spectrum disorder: Diminished judgement of confidence accuracy. Consciousness and Cognition: An International Journal. 2016;42:65–74. doi: http://dx.doi.org/10.1016/j.concog.2016.03.003. X-1, X-3
5210 Granich J, Lin A, Hunt A, . Obesity and associated factors in youth with an autism spectrum disorder. Autism. 2016 Feb 17 doi: 10.1177/1362361315616345. X-1
5211 Grant N, Rodger S, Hoffmann T. Intervention decision-making processes and information preferences of parents of children with autism spectrum disorders. Child: Care, Health and Development. 2016;42(1):125–34. doi: http://dx.doi.org/10.1111/cch.12296. X-1
5212 Gray C, Climie EA. Children with attention deficit/hyperactivity disorder and reading disability: A review of the efficacy of medication treatments. Frontiers in Psychology. 2016;7. X-1, X-226834680
5213 Graziano PA, Garcia A. Attention-deficit hyperactivity disorder and children’s emotion dysregulation: A meta-analysis. Clinical Psychology Review. 2016;46:106–23. doi: http://dx.doi.org/10.1016/j.cpr.2016.04.011. X-1, X-227180913
5214 Green AE, Kenworthy L, Gallagher NM, . Social analogical reasoning in school-aged children with autism spectrum disorder and typically developing peers. Autism. 2016 May 12 doi: 10.1177/1362361316644728. X-1
5215 Green D, Chandler S, Charman T, . Brief Report: DSM-5 Sensory Behaviours in Children With and Without an Autism Spectrum Disorder. J Autism Dev Disord. 2016 Jul 30 doi: 10.1007/s10803-016-2881-7. X-1
5216 Green J, Leadbitter K, Kay C, . Autism spectrum disorder in children adopted after early care breakdown. Journal of Autism and Developmental Disorders. 2016;46(4):1392–402. doi: http://dx.doi.org/10.1007/s10803-015-2680-6. X-126739357
5217 Green JL, Rinehart N, Anderson V, . Association between autism symptoms and family functioning in children with attention-deficit/hyperactivity disorder: a community-based study. Eur Child Adolesc Psychiatry. 2016 May 6 doi: 10.1007/s00787-016-0861-2. X-1
5218 Green JL, Sciberras E, Anderson V, . Association between autism symptoms and functioning in children with ADHD. Arch Dis Child. 2016 Apr 26 doi: 10.1136/archdischild-2015-310257. X-1
5219 Green SA, Hernandez L, Bookheimer SY, . Salience Network Connectivity in Autism Is Related to Brain and Behavioral Markers of Sensory Overresponsivity. J Am Acad Child Adolesc Psychiatry. 2016 Jul;55(7):618–26.e1. doi: 10.1016/j.jaac.2016.04.013. X-127343889
5220 Green Snyder L, D’Angelo D, Chen Q, . Autism Spectrum Disorder, Developmental and Psychiatric Features in 16p11.2 Duplication. J Autism Dev Disord. 2016 May 21 doi: 10.1007/s10803-016-2807-4. X-1
5221 Greenslade KJ, Coggins TE. Brief Report: An Independent Replication and Extension of Psychometric Evidence Supporting the Theory of Mind Inventory. J Autism Dev Disord. 2016 Apr 22 doi: 10.1007/s10803-016-2784-7. X-1
5222 Greer BD, Neidert PL, Dozier CL. A component analysis of toilet-training procedures recommended for young children. Journal of Applied Behavior Analysis. 2016;49(1):69–84. doi: http://dx.doi.org/10.1002/jaba.275. X-126695997
5223 Griguoli M, Sgritta M, Cherubini E. Presynaptic BK channels control transmitter release: physiological relevance and potential therapeutic implications. J Physiol. 2016 Jul 1;594(13):3489–500. doi: 10.1113/jp271841. X-126969302
5224 Grodberg D, Siper P, Jamison J, . A simplified diagnostic observational assessment of autism spectrum disorder in early childhood. Autism Research. 2016;9(4):443–9. doi: http://dx.doi.org/10.1002/aur.1539. X-126305145
5225 Gross C. Defective phosphoinositide metabolism in autism. J Neurosci Res. 2016 Jul 4 doi: 10.1002/jnr.23797. X-1
5226 Grossi E, Melli S, Dunca D, . Unexpected improvement in core autism spectrum disorder symptoms after long-term treatment with probiotics. SAGE Open Med Case Rep. 2016;4:2050313x16666231. doi: 10.1177/2050313x16666231. X-3, X-4
5227 Grossman ES, Hoffman YS, Shrira A. Trauma-Related Context Increases Sleep Disturbances in People with Acute Stress Disorder Symptoms. Stress Health. 2016 Apr 6 doi: 10.1002/smi.2679. X-1
5228 Grzadzinski R, Carr T, Colombi C, . Measuring Changes in Social Communication Behaviors: Preliminary Development of the Brief Observation of Social Communication Change (BOSCC). J Autism Dev Disord. 2016 Jul;46(7):2464–79. doi: 10.1007/s10803-016-2782-9. X-127062034
5229 Grzadzinski R, Dick C, Lord C, . Parent-reported and clinician-observed autism spectrum disorder (ASD) symptoms in children with attention deficit/hyperactivity disorder (ADHD): implications for practice under DSM-5. Mol Autism. 2016;7:7. doi: 10.1186/s13229-016-0072-1. X-126788284
5230 Guardino C, Cannon JE. Deafness and Diversity: Reflections and Directions. Am Ann Deaf. 2016 Spring;161(1):104–12. doi: 10.1353/aad.2016.0016. X-127156921
5231 Guffanti G, Gaudi S, Klengel T, . LINE1 insertions as a genomic risk factor for schizophrenia: Preliminary evidence from an affected family. Am J Med Genet B Neuropsychiatr Genet. 2016 Jun;171(4):534–45. doi: 10.1002/ajmg.b.32437. X-126990047
5232 Guler UO, Yuksel S, Yakici S, . Analysis of the reliability of surgeons’ ability to differentiate between idiopathic and degenerative spinal deformity in adults radiologically. What descriptive parameters help them decide? Eur Spine J. 2016 Jan 14 doi: 10.1007/s00586-015-4366-3. X-1
5233 Gulsrud AC, Hellemann G, Shire S, . Isolating active ingredients in a parent-mediated social communication intervention for toddlers with autism spectrum disorder. J Child Psychol Psychiatry. 2016 May;57(5):606–13. doi: 10.1111/jcpp.12481. X-126525461
5234 Gulsrud AC, Hellemann G, Shire S, . Isolating active ingredients in a parent-mediated social communication intervention for toddlers with autism spectrum disorder. Journal of Child Psychology and Psychiatry. 2016;57(5):606–13. doi: http://dx.doi.org/10.1111/jcpp.12481. X-126525461
5235 Gunn KCM, Delafield-Butt JT. Teaching children with autism spectrum disorder with restricted interests: A review of evidence for best practice. Review of Educational Research. 2016;86(2):408–30. doi: http://dx.doi.org/10.3102/0034654315604027. X-1, X-2
5236 Guo L, Worth AJ, Mesaros C, . Diisopropylethylamine/hexafluoroisopropan ol-mediated ion-pairing ultra-high-performance liquid chromatography/mass spectrometry for phosphate and carboxylate metabolite analysis: utility for studying cellular metabolism. Rapid Commun Mass Spectrom. 2016 Aug 30;30(16):1835–45. doi: 10.1002/rcm.7667. X-127476658
5237 Guo W, Molinaro G, Collins KA, . Selective Disruption of Metabotropic Glutamate Receptor 5-Homer Interactions Mimics Phenotypes of Fragile X Syndrome in Mice. J Neurosci. 2016 Feb 17;36(7):2131–47. doi: 10.1523/jneurosci.2921-15.2016. X-126888925
5238 Guy J, Mottron L, Berthiaume C, . A Developmental Perspective of Global and Local Visual Perception in Autism Spectrum Disorder. J Autism Dev Disord. 2016 Jul 1 doi: 10.1007/s10803-016-2834-1. X-1
5239 Haack LM, Gerdes AC, Lawton KE, . Understanding and measuring functional impairment in diverse children with ADHD: Development of the ADHD-FX scale with an at-risk, community sample. Journal of Attention Disorders. 2016;20(6):487–500. doi: http://dx.doi.org/10.1177/1087054714527791. X-124695438
5240 Haas NA, Soetemann DB, Ates I, . Closure of Secundum Atrial Septal Defects by Using the Occlutech Occluder Devices in More Than 1300 Patients: The IRFACODE Project: A Retrospective Case Series. Catheter Cardiovasc Interv. 2016 Mar 31 doi: 10.1002/ccd.26497. X-1
5241 Habela CW, Song H, Ming GL. Modeling synaptogenesis in schizophrenia and autism using human iPSC derived neurons. Mol Cell Neurosci. 2016 Jun;73:52–62. doi: 10.1016/j.mcn.2015.12.002. X-126655799
5242 Hage A, Banaschewski T, Buitelaar JK, . Glutamatergic medication in the treatment of obsessive compulsive disorder (OCD) and autism spectrum disorder (ASD) - study protocol for a randomised controlled trial. Trials. 2016;17(1):141. doi: 10.1186/s13063-016-1266-8. X-126983548
5243 Hagenaars SP, Harris SE, Davies G, . Shared genetic aetiology between cognitive functions and physical and mental health in UK Biobank (N=112 151) and 24 GWAS consortia. Mol Psychiatry. 2016 Jan 26 doi: 10.1038/mp.2015.225. X-1
5244 Haggarty SJ, Silva MC, Cross A, . Advancing drug discovery for neuropsychiatric disorders using patient-specific stem cell models. Mol Cell Neurosci. 2016 Jun;73:104–15. doi: 10.1016/j.mcn.2016.01.011. X-126826498
5245 Hagmann CE, Wyble B, Shea N, . Children with autism detect targets at very rapid presentation rates with similar accuracy as adults. Journal of Autism and Developmental Disorders. 2016;46(5):1762–72. doi: http://dx.doi.org/10.1007/s10803-016-2705-9. X-1, X-326801777
5246 Haigh SM, Gupta A, Barb SM, . Differential sensory fMRI signatures in autism and schizophrenia: Analysis of amplitude and trial-to-trial variability. Schizophr Res. 2016 Apr 12 doi: 10.1016/j.schres.2016.03.036. X-1
5247 Haker H, Schneebeli M, Stephan KE. Can Bayesian Theories of Autism Spectrum Disorder Help Improve Clinical Practice? Front Psychiatry. 2016;7:107. doi: 10.3389/fpsyt.2016.00107. X-127378955
5248 Hall CL, Valentine AZ, Groom MJ, . The clinical utility of the continuous performance test and objective measures of activity for diagnosing and monitoring ADHD in children: A systematic review. European Child & Adolescent Psychiatry. 2016;25(7):677–99. doi: http://dx.doi.org/10.1007/s00787-015-0798-x. X-1, X-226620873
5249 Hall DA, Robertson E, Shelton AL, . Update on the Clinical, Radiographic, and Neurobehavioral Manifestations in FXTAS and FMR1 Premutation Carriers. Cerebellum. 2016 Jun 10 doi: 10.1007/s12311-016-0799-4. X-1
5250 Hall SS, Wright HF, Mills DS. What Factors Are Associated with Positive Effects of Dog Ownership in Families with Children with Autism Spectrum Disorder? The Development of the Lincoln Autism Pet Dog Impact Scale. PLoS One. 2016;11(2):e0149736. doi: 10.1371/journal.pone.0149736. X-126894820
5251 Halpin J. What do nurses think they are doing in pre-school autism assessment? Br J Nurs. 2016 Mar 24–Apr 13;25(6):319–23. doi: 10.12968/bjon.2016.25.6.319. X-127019169
5252 Hames EC, Murphy B, Rajmohan R, . Visual, Auditory, and Cross Modal Sensory Processing in Adults with Autism: An EEG Power and BOLD fMRI Investigation. Front Hum Neurosci. 2016;10:167. doi: 10.3389/fnhum.2016.00167. X-127148020
5253 Hamilton DK, Kanter AS, Bolinger BD, . Reoperation rates in minimally invasive, hybrid and open surgical treatment for adult spinal deformity with minimum 2-year follow-up. Eur Spine J. 2016 Feb 24 doi: 10.1007/s00586-016-4443-2. X-1
5254 Hamilton J, Stevens G, Girdler S. Becoming a Mentor: The Impact of Training and the Experience of Mentoring University Students on the Autism Spectrum. PLoS One. 2016;11(4):e0153204. doi: 10.1371/journal.pone.0153204. X-127070418
5255 Hampton LH, Kaiser AP. Intervention effects on spoken-language outcomes for children with autism: A systematic review and meta-analysis. Journal of Intellectual Disability Research. 2016;60(5):444–63. doi: http://dx.doi.org/10.1111/jir.12283. X-227120988
5256 Han Y, Sun J, Luo C, . Comparison of pedicle screw-based dynamic stabilization and fusion surgery in the treatment of radiographic adjacent-segment degeneration: a retrospective analysis of single L5-S1 degenerative spondylosis covering 4 years. J Neurosurg Spine. 2016 Jun 24:1–7. doi: 10.3171/2016.4.spine1679. X-126360143
5257 Hanaie R, Mohri I, Kagitani-Shimono K, . White matter volume in the brainstem and inferior parietal lobule is related to motor performance in children with autism spectrum disorder: A voxel-based morphometry study. Autism Res. 2016 Jan 25 doi: 10.1002/aur.1605. X-1
5258 Hanamsagar R, Bilbo SD. Sex differences in neurodevelopmental and neurodegenerative disorders: Focus on microglial function and neuroinflammation during development. J Steroid Biochem Mol Biol. 2016 Jun;160:127–33. doi: 10.1016/j.jsbmb.2015.09.039. X-1, X-2, X-3, X-426435451
5259 Haraya S, Karasawa K, Sano Y, . Development of a highly specific enzyme immunoassay for oxytocin and its use in plasma samples. Ann Clin Biochem. 2016 May 10 doi: 10.1177/0004563216645122. X-1
5260 Hardan AY, Fung LK, Frazier T, . A proton spectroscopy study of white matter in children with autism. Progress in Neuro-Psychopharmacology & Biological Psychiatry. 2016;66:48–53. doi: http://dx.doi.org/10.1016/j.pnpbp.2015.11.005. X-126593330
5261 Harden SW, Frazier CJ. Oxytocin Depolarizes Fast-Spiking Hilar Interneurons and Induces GABA Release onto Mossy Cells of the Rat Dentate Gyrus. Hippocampus. 2016 Apr 12 doi: 10.1002/hipo.22595. X-1
5262 Hare DJ, Gracey C, Wood C. Anxiety in high-functioning autism: A pilot study of experience sampling using a mobile platform. Autism. 2016 Aug;20(6):730–43. doi: 10.1177/1362361315604817. X-126514793
5263 Harker CM, Ibañez LV, Nguyen TP, . The effect of parenting style on social smiling in infants at high and low risk for ASD. Journal of Autism and Developmental Disorders. 2016;46(7):2399–407. doi: http://dx.doi.org/10.1007/s10803-016-2772-y. X-127007726
5264 Harkin LF, Gerrelli D, Gold Diaz DC, . Distinct expression patterns for type II topoisomerases IIA and IIB in the early foetal human telencephalon. J Anat. 2016 Mar;228(3):452–63. doi: 10.1111/joa.12416. X-126612825
5265 Harmon P, Galipeau K, Xu W, . Mechanism of Dissolution-Induced Nanoparticle Formation from a Copovidone-Based Amorphous Solid Dispersion. Mol Pharm. 2016 May 2;13(5):1467–81. doi: 10.1021/acs.molpharmaceut.5b00863. X-127019407
5266 Harriage B, Blair KS, Miltenberger R. An Evaluation of a Parent Implemented In Situ Pedestrian Safety Skills Intervention for Individuals with Autism. J Autism Dev Disord. 2016 Jun;46(6):2017–27. doi: 10.1007/s10803-016-2730-8. X-1, X-326864158
5267 Harrison AJ, Long KA, Manji KP, . Development of a Brief Intervention to Improve Knowledge of Autism and Behavioral Strategies Among Parents in Tanzania. Intellect Dev Disabil. 2016 Jun;54(3):187–201. doi: 10.1352/1934-9556-54.3.187. X-127268474
5268 Harrison AJ, Lu Z, McLean RL, . Cognitive and adaptive correlates of an ADOS-derived joint attention composite. Research in Autism Spectrum Disorders. 2016;29–30:66–78. doi: http://dx.doi.org/10.1016/j.rasd.2016.07.001. X-1
5269 Harrison AJ, Slane MM, Hoang L, . An international review of autism knowledge assessment measures. Autism. 2016 May 5 doi: 10.1177/1362361316638786. X-1
5270 Harrop C, Green J, Hudry K. Play complexity and toy engagement in preschoolers with autism spectrum disorder: Do girls and boys differ? Autism. 2016 Mar 2 doi: 10.1177/1362361315622410. X-1
5271 Harrop C, Gulsrud A, Shih W, . Characterizing caregiver responses to restricted and repetitive behaviors in toddlers with autism spectrum disorder. Autism. 2016;20(3):330–42. doi: http://dx.doi.org/10.1177/1362361315580443. X-125948600
5272 Harrop C, McBee M, Boyd BA. How are child restricted and repetitive behaviors associated with caregiver stress over time? A parallel process multilevel growth model. Journal of Autism and Developmental Disorders. 2016;46(5):1773–83. doi: http://dx.doi.org/10.1007/s10803-016-2707-7. X-126801776
5273 Harstad E, Blum N, Gahman A, . Management of Attention-Deficit/Hyperactivity Disorder by Developmental-Behavioral Pediatricians: A DBPNet Study. J Dev Behav Pediatr. 2016 Jul 13 doi: 10.1097/dbp.0000000000000329. X-1
5274 Hartley SL, Papp LM, Blumenstock SM, . The Effect of Daily Challenges in Children With Autism on Parents’ Couple Problem-Solving Interactions. J Fam Psychol. 2016 Jun 23 doi: 10.1037/fam0000219. X-1
5275 Hartley SL, Papp LM, Bolt D. Spillover of Marital Interactions and Parenting Stress in Families of Children With Autism Spectrum Disorder. J Clin Child Adolesc Psychol. 2016 May 24:1–12. doi: 10.1080/15374416.2016.1152552. X-1
5276 Hashemi E, Ariza J, Rogers H, . The Number of Parvalbumin-Expressing Interneurons Is Decreased in the Medial Prefrontal Cortex in Autism. Cereb Cortex. 2016 Feb 27 doi: 10.1093/cercor/bhw021. X-1
5277 Hashimoto R, Nakazawa T, Tsurusaki Y, . Whole-exome sequencing and neurite outgrowth analysis in autism spectrum disorder. J Hum Genet. 2016 Mar;61(3):199–206. doi: 10.1038/jhg.2015.141. X-126582266
5278 Hatakenaka Y, Fernell E, Sakaguchi M, . ESSENCE-Q - a first clinical validation study of a new screening questionnaire for young children with suspected neurodevelopmental problems in south Japan. Neuropsychiatr Dis Treat. 2016;12:1739–46. doi: 10.2147/ndt.s108411. X-127478377
5279 Hatakenaka Y, Fernell E, Sakaguchi M, . ESSENCE-Q—A first clinical validation study of a new screening questionnaire for young children with suspected neurodevelopmental problems in south Japan Neuropsychiatric Disease and Treatment. 2016;12. X-1
5280 Havdahl KA, von Tetzchner S, Huerta M, . Utility of the child behavior checklist as a screener for autism spectrum disorder. Autism Research. 2016;9(1):33–42. doi: http://dx.doi.org/10.1002/aur.1515. X-126140652
5281 Heaton TJ, Freeth M. Reduced visual exploration when viewing photographic scenes in individuals with autism spectrum disorder. Journal of Abnormal Psychology. 2016;125(3):399–411. doi: http://dx.doi.org/10.1037/abn0000145. X-126915060
5282 Hebron J, Oldfield J, Humphrey N. Cumulative risk effects in the bullying of children and young people with autism spectrum conditions. Autism. 2016 Apr 19 doi: 10.1177/1362361316636761. X-1
5283 Hecht PM, Hudson M, Connors SL, . Maternal serotonin transporter genotype affects risk for ASD with exposure to prenatal stress. Autism Res. 2016 Apr 19 doi: 10.1002/aur.1629. X-1
5284 Hedley D. New rapid autism screening test. J Pediatr. 2016 Jan;168:255–6. doi: 10.1016/j.jpeds.2015.10.075. X-1
5285 Hedley D, Brewer N, Nevill R, . The relationship between clinicians’ confidence and accuracy, and the influence of child characteristics, in the screening of autism spectrum disorder. Journal of Autism and Developmental Disorders. 2016;46(7):2340–8. doi: http://dx.doi.org/10.1007/s10803-016-2766-9. X-126975451
5286 Heifert TA, Susi A, Hisle-Gorman E, . Feeding Disorders in Children with Autism Spectrum Disorders Are Associated with Eosinophilic Esophagitis. J Pediatr Gastroenterol Nutr. 2016 Jun 8 doi: 10.1097/mpg.0000000000001282. X-1
5287 Heimann M, Nordqvist E, Strid K, . Children with autism respond differently to spontaneous, elicited and deferred imitation. Journal of Intellectual Disability Research. 2016;60(5):491–501. doi: http://dx.doi.org/10.1111/jir.12272. X-1, X-327018212
5288 Heinen CA, Jongejan A, Watson PJ, . A specific mutation in TBL1XR1 causes Pierpont syndrome. J Med Genet. 2016 May;53(5):330–7. doi: 10.1136/jmedgenet-2015-103233. X-126769062
5289 Helland WA, Posserud M-B, Helland T, . Language impairments in children with ADHD and in children with reading disorder. Journal of Attention Disorders. 2016;20(7):581–9. doi: http://dx.doi.org/10.1177/1087054712461530. X-123074303
5290 Helles A, Gillberg IC, Gillberg C, . Asperger syndrome in males over two decades: Quality of life in relation to diagnostic stability and psychiatric comorbidity. Autism. 2016 May 26 doi: 10.1177/1362361316650090. X-1
5291 Hellmuth SG, Pedersen LH, Miltoft CB, . Increased nuchal translucency thickness and the risk of neurodevelopmental disorders. Ultrasound Obstet Gynecol. 2016 May 17 doi: 10.1002/uog.15961. X-1
5292 Helt MS, Fein DA. Facial feedback and social input: Effects on laughter and enjoyment in children with autism spectrum disorders. Journal of Autism and Developmental Disorders. 2016;46(1):83–94. doi: http://dx.doi.org/10.1007/s10803-015-2545-z. X-126254892
5293 Hemmingsson H, Olafsdottir LB, Egilson ST. Agreements and disagreements between children and their parents in health-related assessments. Disabil Rehabil. 2016 Jun 13:1–14. doi: 10.1080/09638288.2016.1189603. X-1, X-2
5294 Hendren RL, James SJ, Widjaja F, . Randomized, Placebo-Controlled Trial of Methyl B12 for Children with Autism. J Child Adolesc Psychopharmacol. 2016 Feb 18 doi: 10.1089/cap.2015.0159.
5295 Hendriksen JG, Vles JS. Muscle and brain: a dyad with important diagnostic and therapeutic implications. Dev Med Child Neurol. 2016 Jan;58(1):13. doi: 10.1111/dmcn.12937. X-126456166
5296 Hendy H, Harclerode W, Williams KE. The Parent Mealtime Action Scale revised (PMAS-R): Psychometric characteristics and associations with variables of clinical interest. Appetite. 2016 May 21;105:283–90. doi: 10.1016/j.appet.2016.05.025. X-127221356
5297 Henning B, Cordier R, Wilkes-Gillan S, . A pilot play-based intervention to improve the social play interactions of children with autism spectrum disorder and their typically developing playmates. Aust Occup Ther J. 2016 Apr 26 doi: 10.1111/1440-1630.12285. X-3, X-4
5298 Hens K, Peeters H, Dierickx K. Genetic testing and counseling in the case of an autism diagnosis: A caregivers perspective. Eur J Med Genet. 2016 Aug 17;59(9):452–8. doi: 10.1016/j.ejmg.2016.08.007. X-127544064
5299 Heon E, Kim G, Qin S, . Mutations in C8ORF37 cause Bardet Biedl syndrome (BBS21). Hum Mol Genet. 2016 Mar 22 doi: 10.1093/hmg/ddw096. X-1
5300 Herpers PCM, Klip H, Rommelse NNJ, . Associations between high callous–unemotional traits and quality of life across youths with non-conduct disorder diagnoses. European Child & Adolescent Psychiatry. 2016;25(5):547–55. doi: http://dx.doi.org/10.1007/s00787-015-0766-5. X-126362863
5301 Herrick RT, Tavarez MA, Harsh BN, . Effect of immunological castration management strategy on lipid oxidation and sensory characteristics of bacon stored under simulated food service conditions. J Anim Sci. 2016 Jul;94(7):3084–92. doi: 10.2527/jas.2016-0366. X-127482695
5302 Herringshaw AJ, Ammons CJ, DeRamus TP, . Hemispheric differences in language processing in autism spectrum disorders: A meta-analysis of neuroimaging studies. Autism Res. 2016 Jan 11 doi: 10.1002/aur.1599. X-1, X-2
5303 Hessl D, Grigsby J. Fragile X-associated tremor/ataxia syndrome: another phenotype of the fragile X gene. Clin Neuropsychol. 2016 Jun 29:1–5. doi: 10.1080/13854046.2016.1186661. X-1
5304 Heunis TM, Aldrich C, de Vries PJ. Recent Advances in Resting-State Electroencephalography Biomarkers for Autism Spectrum Disorder-A Review of Methodological and Clinical Challenges. Pediatr Neurol. 2016 Apr 1 doi: 10.1016/j.pediatrneurol.2016.03.010. X-1
5305 Hewavitharana SS, Mazzola M. Carbon source-dependent effects of anaerobic soil disinfestation on soil microbiome and suppression of Rhizoctonia solani AG-5 and Pratylenchus penetrans. Phytopathology. 2016 May 4 doi: 10.1094/phyto-12-15-0329-r. X-1
5306 Hewitt A, Hall-Lande J, Hamre K, . Autism Spectrum Disorder (ASD) Prevalence in Somali and Non-Somali Children. J Autism Dev Disord. 2016 Apr 22 doi: 10.1007/s10803-016-2793-6. X-1
5307 Heys M, Alexander A, Medeiros E, . Understanding parents’ and professionals’ knowledge and awareness of autism in Nepal. Autism. 2016 May 19 doi: 10.1177/1362361316646558. X-1
5308 Hidding E, Swaab H, de Sonneville LM, . The role of COMT and plasma proline in the variable penetrance of autistic spectrum symptoms in 22q11.2 Deletion Syndrome. Clin Genet. 2016 Feb 26 doi: 10.1111/cge.12766. X-1
5309 Higbee TS, Aporta AP, Resende A, . Interactive computer training to teach discrete-trial instruction to undergraduates and special educators in Brazil: A replication and extension. J Appl Behav Anal. 2016 Jun 17 doi: 10.1002/jaba.329. X-1
5310 Higuchi Y, Inagaki M, Koyama T, . A cross-sectional study of psychological distress, burnout, and the associated risk factors in hospital pharmacists in Japan. BMC Public Health. 2016;16:534. doi: 10.1186/s12889-016-3208-5. X-127392676
5311 Hilvert E, Davidson D, Gámez PB. Examination of script and non-script based narrative retellings in children with autism spectrum disorders. Research in Autism Spectrum Disorders. 2016;29–30:79–92. doi: http://dx.doi.org/10.1016/j.rasd.2016.06.002. X-1, X-3
5312 Hiniker A, Rosenberg-Lee M, Menon V. Distinctive role of symbolic number sense in mediating the mathematical abilities of children with autism. Journal of Autism and Developmental Disorders. 2016;46(4):1268–81. doi: http://dx.doi.org/10.1007/s10803-015-2666-4. X-126659551
5313 Hippolyte L, Maillard AM, Rodriguez-Herreros B, . The number of genomic copies at the 16p11.2 locus modulates language, verbal memory, and inhibition. Biological Psychiatry. 2016;80(2):129–39. doi: http://dx.doi.org/10.1016/j.biopsych.2015.10.021. X-126742926
5314 Hoch J, Spofford L, Dimian A, . A direct comparison of self-injurious and stereotyped motor behavior between preschool-aged children with and without developmental delays. Journal of Pediatric Psychology. 2016;41(5):566–72. doi: http://dx.doi.org/10.1093/jpepsy/jsv102. X-126514642
5315 Hochstenbach R, Nowakowska B, Volleth M, . Multiple Small Supernumerary Marker Chromosomes Resulting from Maternal Meiosis I or II Errors. Mol Syndromol. 2016 Feb;6(5):210–21. doi: 10.1159/000441408. X-126997941
5316 Hodgetts S, Park E. Preparing for the future: a review of tools and strategies to support autonomous goal setting for children and youth with autism spectrum disorders. Disabil Rehabil. 2016 Mar 30:1–9. doi: 10.3109/09638288.2016.1161084. X-1, X-2
5317 Hodgson AR, Freeston MH, Honey E, . Facing the Unknown: Intolerance of Uncertainty in Children with Autism Spectrum Disorder. J Appl Res Intellect Disabil. 2016 Feb 12 doi: 10.1111/jar.12245. X-1
5318 Hofer J, Hoffmann F, Bachmann C. Use of complementary and alternative medicine in children and adolescents with autism spectrum disorder: A systematic review. Autism. 2016 May 25 doi: 10.1177/1362361316646559. X-1, X-2
5319 Hoffman EJ, Turner KJ, Fernandez JM, . Estrogens Suppress a Behavioral Phenotype in Zebrafish Mutants of the Autism Risk Gene, CNTNAP2. Neuron. 2016 Feb 17;89(4):725–33. doi: 10.1016/j.neuron.2015.12.039. X-126833134
5320 Hoffmann E, Bruck C, Kreifelts B, . Reduced functional connectivity to the frontal cortex during processing of social cues in autism spectrum disorder. J Neural Transm (Vienna). 2016 Apr 19 doi: 10.1007/s00702-016-1544-3. X-1
5321 Hoffmann W, Weber L, König U, . The role of the CBCL in the assessment of autism spectrum disorders: An evaluation of symptom profiles and screening characteristics. Research in Autism Spectrum Disorders. 2016;27:44–53. doi: http://dx.doi.org/10.1016/j.rasd.2016.04.002. X-1
5322 Hoglund Carlsson L, Saltvedt S, Anderlid BM, . Ultrasound in the first and second trimester and autism; a prospective randomized study. Ultrasound Obstet Gynecol. 2016 May 17 doi: 10.1002/uog.15962. X-1
5323 Höher Camargo SP, Rispoli M, Ganz J, . Behaviorally based interventions for teaching social interaction skills to children with ASD in inclusive settings: A meta-analysis. Journal of Behavioral Education. 2016;25(2):223–48. doi: http://dx.doi.org/10.1007/s10864-015-9240-1. X-2
5324 Holbrook JR, Cuffe SP, Cai B, . Persistence of parent-reported ADHD symptoms from childhood through adolescence in a community sample. Journal of Attention Disorders. 2016;20(1):11–20. doi: http://dx.doi.org/10.1177/1087054714539997. X-124994874
5325 Hollway JA, Aman MG, Mendoza-Burcham MI, . Caregiver Satisfaction with a Multisite Trial of Atomoxetine and Parent Training for Attention-Deficit/Hyperactivity Disorder and Behavioral Noncompliance in Children with Autism Spectrum Disorder. J Child Adolesc Psychopharmacol. 2016 Jan 21 doi: 10.1089/cap.2015.0130. X-1
5326 Holmes LG, Himle MB, Strassberg DS. Parental romantic expectations and parent-child sexuality communication in autism spectrum disorders. Autism. 2016 Aug;20(6):687–99. doi: 10.1177/1362361315602371. X-126408632
5327 Holmes LG, Himle MB, Strassberg DS. Parental romantic expectations and parent–child sexuality communication in autism spectrum disorders. Autism. 2016;20(6):687–99. doi: http://dx.doi.org/10.1177/1362361315602371. X-126408632
5328 Holmes LG, Himle MB, Strassberg DS. Parental sexuality-related concerns for adolescents with autism spectrum disorders and average or above IQ. Research in Autism Spectrum Disorders. 2016;21:84–93. doi: http://dx.doi.org/10.1016/j.rasd.2015.10.001. X-1
5329 Holt V, Skagerberg E, Dunsford M. Young people with features of gender dysphoria: Demographics and associated difficulties. Clinical Child Psychology and Psychiatry. 2016;21(1):108–18. doi: http://dx.doi.org/10.1177/1359104514558431. X-125431051
5330 Homberg JR, Kyzar EJ, Scattoni ML, . Genetic and environmental modulation of neurodevelopmental disorders: Translational insights from labs to beds. Brain Res Bull. 2016 Apr 23;125:79–91. doi: 10.1016/j.brainresbull.2016.04.015. X-127113433
5331 Honeycutt JA, Keary Iii KM, Kania VM, . Developmental Age Differentially Mediates the Calcium-Binding Protein Parvalbumin in the Rat: Evidence for a Selective Decrease in Hippocampal Parvalbumin Cell Counts. Dev Neurosci. 2016;38(2):105–14. doi: 10.1159/000444447. X-127002731
5332 Hong ER, Ganz JB, Mason R, . The effects of video modeling in teaching functional living skills to persons with ASD: A meta-analysis of single-case studies. Res Dev Disabil. 2016 Jul 18;57:158–69. doi: 10.1016/j.ridd.2016.07.001. X-1, X-227442687
5333 Hong ER, Ganz JB, Neely L, . A review of the quality of primary caregiver-implemented communication intervention research for children with ASD. Research in Autism Spectrum Disorders. 2016;25:122–36. doi: http://dx.doi.org/10.1016/j.rasd.2016.02.005. X-1, X-2, X-3
5334 Hong H, Kim BS, Im HI. Pathophysiological Role of Neuroinflammation in Neurodegenerative Diseases and Psychiatric Disorders. Int Neurourol J. 2016 May;20(Suppl 1):S2–7. doi: 10.5213/inj.1632604.302. X-127230456
5335 Honkasilta J, Vehmas S, Vehkakoski T. Self-pathologizing, self-condemning, self-liberating: Youths’ accounts of their ADHD-related behavior. Social Science & Medicine. 2016;150:248–55. doi: http://dx.doi.org/10.1016/j.socscimed.2015.12.030. X-126774711
5336 Hopf KP, Madren E, Santianni KA. Use and Perceived Effectiveness of Complementary and Alternative Medicine to Treat and Manage the Symptoms of Autism in Children: A Survey of Parents in a Community Population. J Altern Complement Med. 2016 Jan;22(1):25–32. doi: 10.1089/acm.2015.0163. X-1, X-326654976
5337 Hopkins Z, Yuill N, Keller B. Children with autism align syntax in natural conversation. Applied Psycholinguistics. 2016;37(2):347–70. doi: http://dx.doi.org/10.1017/S0142716414000599. X-1
5338 Horvath G, Petrovszki Z, Kekesi G, . Electrophysiological alterations in a complex rat model of schizophrenia. Behav Brain Res. 2016 Jul 1;307:65–72. doi: 10.1016/j.bbr.2016.03.051. X-127036646
5339 House SA, Goodman DC, Weinstein SJ, . Prescription Use among Children with Autism Spectrum Disorders in Northern New England: Intensity and Small Area Variation. J Pediatr. 2016 Feb;169:277–83.e2. doi: 10.1016/j.jpeds.2015.10.027. X-126561379
5340 Howe FE, Stagg SD. Erratum to: How Sensory Experiences Affect Adolescents with an Autistic Spectrum Condition within the Classroom. J Autism Dev Disord. 2016 Jun;46(6):2273. doi: 10.1007/s10803-016-2791-8. X-127101236
5341 Howe FEJ, Stagg SD. How sensory experiences affect adolescents with an autistic spectrum condition within the classroom. Journal of Autism and Developmental Disorders. 2016;46(5):1656–68. doi: http://dx.doi.org/10.1007/s10803-015-2693-1. X-126791372
5342 Howie EK, Campbell AC, Straker LM. An active video game intervention does not improve physical activity and sedentary time of children at-risk for developmental coordination disorder: A crossover randomized trial. Child: Care, Health and Development. 2016;42(2):253–60. doi: http://dx.doi.org/10.1111/cch.12305. X-1
5343 Hrdlicka M, Vacova M, Oslejskova H, . Age at diagnosis of autism spectrum disorders: is there an association with socioeconomic status and family self-education about autism? Neuropsychiatr Dis Treat. 2016;12:1639–44. doi: 10.2147/ndt.s107239. X-127462156
5344 Hsiao K, Harony-Nicolas H, Buxbaum JD, . Cyfip1 Regulates Presynaptic Activity during Development. J Neurosci. 2016 Feb 3;36(5):1564–76. doi: 10.1523/jneurosci.0511-15.2016. X-126843638
5345 Huang CT, Chiang CH, Hung CY. Young children with autism spectrum disorders imitate in the context of others’ prior intention. Autism. 2016 Apr 5 doi: 10.1177/1362361315627135. X-1
5346 Huang JY, Tian Y, Wang HJ, . Functional Genomic Analyses Identify Pathways Dysregulated in Animal Model of Autism. CNS Neurosci Ther. 2016 Jun 20 doi: 10.1111/cns.12582. X-1
5347 Hubner LM, Feldman HM, Huffman LC. Parent-reported shared decision making: Autism spectrum disorder and other neurodevelopmental disorders. Journal of Developmental and Behavioral Pediatrics. 2016;37(1):20–32. X-126703325
5348 Huijnen CA, Lexis MA, Jansens R, . Mapping Robots to Therapy and Educational Objectives for Children with Autism Spectrum Disorder. J Autism Dev Disord. 2016 Jun;46(6):2100–14. doi: 10.1007/s10803-016-2740-6. X-1, X-326909762
5349 Humphreys KL, Galán CA, Tottenham N, . Impaired social decision-making mediates the association between ADHD and social problems. Journal of Abnormal Child Psychology. 2016;44(5):1023–32. doi: http://dx.doi.org/10.1007/s10802-015-0095-7. X-126486935
5350 Hundley RJ, Shui A, Malow BA. Relationship Between Subtypes of Restricted and Repetitive Behaviors and Sleep Disturbance in Autism Spectrum Disorder. J Autism Dev Disord. 2016 Aug 10 doi: 10.1007/s10803-016-2884-4. X-1
5351 Hunter JE, Irving SA, Biesecker LG, . A standardized, evidence-based protocol to assess clinical actionability of genetic disorders associated with genomic variation. Genet Med. 2016 Apr 28 doi: 10.1038/gim.2016.40. X-1
5352 Husk JS, Keim SA. Breastfeeding and dietary variety among preterm children aged 1–3 years. Appetite. 2016;99:130–7. doi: http://dx.doi.org/10.1016/j.appet.2016.01.016. X-126792771
5353 Hutchins TL, Brien A. Conversational topic moderates social attention in autism spectrum disorder: Talking about emotions is like driving in a snowstorm. Research in Autism Spectrum Disorders. 2016;26:99–110. doi: http://dx.doi.org/10.1016/j.rasd.2016.03.006. X-1
5354 Hutchins TL, Prelock PA, Morris H, . Explicit vs. applied theory of mind competence: A comparison of typically developing males, males with ASD, and males with ADHD. Research in Autism Spectrum Disorders. 2016;21:94–108. doi: http://dx.doi.org/10.1016/j.rasd.2015.10.004. X-1
5355 Hutsler JJ, Casanova MF. Review: Cortical construction in autism spectrum disorder: columns, connectivity and the subplate. Neuropathol Appl Neurobiol. 2016 Feb;42(2):115–34. doi: 10.1111/nan.12227. X-125630827
5356 Huynh K. Antiplatelet therapy: Clopidogrel plus aspirin reduces migrane attacks after ASD closure. Nat Rev Cardiol. 2016 Jan;13(1):2. doi: 10.1038/nrcardio.2015.186. X-1
5357 Hwang S-K, Lee J-H, Yang J-e, . Everolimus improves neuropsychiatric symptoms in a patient with tuberous sclerosis carrying a novel TSC2 mutation. Molecular Brain. 2016;9. X-126819004
5358 Iacobucci G. Government slow to improve services for people with learning disabilities, report finds. Bmj. 2016;352:i1118. doi: 10.1136/bmj.i1118. X-126905485
5359 Igelstrom KM, Webb TW, Graziano MS. Functional Connectivity Between the Temporoparietal Cortex and Cerebellum in Autism Spectrum Disorder. Cereb Cortex. 2016 Apr 12 doi: 10.1093/cercor/bhw079. X-1
5360 Iijima Y, Behr K, Iijima T, . Distinct Defects in Synaptic Differentiation of Neocortical Neurons in Response to Prenatal Valproate Exposure. Sci Rep. 2016;6:27400. doi: 10.1038/srep27400. X-127264355
5361 Ikejiri K, Hosozawa M, Mitomo S, . Reduced growth during early infancy in very low birth weight children with autism spectrum disorder. Early Hum Dev. 2016 Jun 28;98:23–7. doi: 10.1016/j.earlhumdev.2016.05.001. X-127367970
5362 Imagama S, Kawakami N, Kanemura T, . Radiographic Adjacent Segment Degeneration at Five Years After L4/5 Posterior Lumbar Interbody Fusion With Pedicle Screw Instrumentation: Evaluation by Computed Tomography and Annual Screening With Magnetic Resonance Imaging. Clin Spine Surg. 2016 May 2 doi: 10.1097/BSD.0b013e31828aec78. X-1
5363 Imms C, Adair B, Keen D, . ‘Participation’: a systematic review of language, definitions, and constructs used in intervention research with children with disabilities. Dev Med Child Neurol. 2016 Jan;58(1):29–38. doi: 10.1111/dmcn.12932. X-1, X-226411643
5364 Inami S, Moridaira H, Takeuchi D, . Optimum pelvic incidence minus lumbar lordosis value can be determined by individual pelvic incidence. Eur Spine J. 2016 Apr 12 doi: 10.1007/s00586-016-4563-8. X-1
5365 Inan M, Zhao M, Manuszak M, . Energy deficit in parvalbumin neurons leads to circuit dysfunction, impaired sensory gating and social disability. Neurobiol Dis. 2016 Sep;93:35–46. doi: 10.1016/j.nbd.2016.04.004. X-127105708
5366 Ingersoll B, Wainer AL, Berger NI, . Comparison of a Self-Directed and Therapist-Assisted Telehealth Parent-Mediated Intervention for Children with ASD: A Pilot RCT. J Autism Dev Disord. 2016 Jul;46(7):2275–84. doi: 10.1007/s10803-016-2755-z. X-126922192
5367 Inskip M, Mavros Y, Sachdev PS, . Exercise for Individuals with Lewy Body Dementia: A Systematic Review. PLoS One. 2016;11(6):e0156520. doi: 10.1371/journal.pone.0156520. X-127258533
5368 Ionita-Laza I, McCallum K, Xu B, . A spectral approach integrating functional genomic annotations for coding and noncoding variants. Nat Genet. 2016 Feb;48(2):214–20. doi: 10.1038/ng.3477. X-126727659
5369 Iorio JA, Reid P, Kim HJ. Neurological complications in adult spinal deformity surgery. Curr Rev Musculoskelet Med. 2016 Jun 1 doi: 10.1007/s12178-016-9350-y. X-1
5370 Irvine CA, Eigsti I-M, Fein DA. Uh, um, and autism: Filler disfluencies as pragmatic markers in adolescents with optimal outcomes from autism spectrum disorder. Journal of Autism and Developmental Disorders. 2016;46(3):1061–70. doi: http://dx.doi.org/10.1007/s10803-015-2651-y. X-126586555
5371 Ishizuka Y, Yamamoto JI. Contingent imitation increases verbal interaction in children with autism spectrum disorders. Autism. 2016 Apr 19 doi: 10.1177/1362361315622856. X-1
5372 Isles AR, Ingason A, Lowther C, . Parental Origin of Interstitial Duplications at 15q11.2-q13.3 in Schizophrenia and Neurodevelopmental Disorders. PLoS Genet. 2016 May;12(5):e1005993. doi: 10.1371/journal.pgen.1005993. X-127153221
5373 Ito S. GABA and glycine in the developing brain. J Physiol Sci. 2016 Mar 7 doi: 10.1007/s12576-016-0442-7. X-1
5374 Jacobs M, Woolfson LM, Hunter SC. Attributions of stability, control and responsibility: How parents of children with intellectual disabilities view their child’s problematic behaviour and its causes. Journal of Applied Research in Intellectual Disabilities. 2016;29(1):58–70. doi: http://dx.doi.org/10.1111/jar.12158. X-125753834
5375 Jain A, Lafage V, Kelly MP, . Validity, Reliability, and Responsiveness of SRS-7 as an Outcomes Assessment Instrument for Operatively Treated Patients with Adult Spinal Deformity. Spine (Phila Pa 1976). 2016 Feb 29 doi: 10.1097/brs.0000000000001540. X-1
5376 Jain A, Marshall J, Buikema A, . Correction of Description of MMR Vaccine Receipt Coding and Minor Errors in MMR Vaccine and Autism Study. Jama. 2016 Jan 12;315(2):202–4. doi: 10.1001/jama.2015.17065. X-1
5377 Jakobsen KD, Bruhn CH, Pagsberg AK, . Neurological, Metabolic, and Psychiatric Adverse Events in Children and Adolescents Treated With Aripiprazole. J Clin Psychopharmacol. 2016 Aug 6 doi: 10.1097/jcp.0000000000000548. X-1, X-3
5378 Jalai CM, Passias PG, Lafage V, . A comparative analysis of the prevalence and characteristics of cervical malalignment in adults presenting with thoracolumbar spine deformity based on variations in treatment approach over 2 years. Eur Spine J. 2016 Apr 13 doi: 10.1007/s00586-016-4564-7. X-1
5379 Jalal Z, Hascoet S, Baruteau AE, . Long-term Complications After Transcatheter Atrial Septal Defect Closure: A Review of the Medical Literature. Can J Cardiol. 2016 Mar 3 doi: 10.1016/j.cjca.2016.02.068. X-1
5380 Jao Keehn RJ, Sanchez SS, Stewart CR, . Impaired downregulation of visual cortex during auditory processing is associated with autism symptomatology in children and adolescents with autism spectrum disorder. Autism Res. 2016 May 20 doi: 10.1002/aur.1636. X-1
5381 Jarczok TA, Fritsch M, Kroger A, . Maturation of interhemispheric signal propagation in autism spectrum disorder and typically developing controls: a TMS-EEG study. J Neural Transm (Vienna). 2016 May 13 doi: 10.1007/s00702-016-1550-5. X-1
5382 Jarrett MA, Gilpin AT, Pierucci JM, . Cognitive and reactive control processes: Associations with ADHD symptoms in preschoolers. International Journal of Behavioral Development. 2016;40(1):53–7. doi: http://dx.doi.org/10.1177/0165025415575625. X-1
5383 Jeevanantham D, Bartlett D. Perspectives on classification of selected childhood neurodisabilities based on a review of literature. Dev Neurorehabil. 2016 Apr 8:1–13. doi: 10.3109/17518423.2016.1139009. X-1, X-2
5384 Jenkins DD, Wiest DB, Mulvihill DM, . Fetal and Neonatal Effects of N-Acetylcysteine When Used for Neuroprotection in Maternal Chorioamnionitis. J Pediatr. 2016 Jan;168:67–76.e6. doi: 10.1016/j.jpeds.2015.09.076. X-126545726
5385 Jeon JP, Cho YD, Han MH. Intra-arterial thrombolysis of central retinal artery occlusion following percutaneous atrial septal defect closure. Catheter Cardiovasc Interv. 2016 Jul;88(1):157–60. doi: 10.1002/ccd.26100. X-126153142
5386 Jessel J, Hanley GP, Ghaemmaghami M. A translational evaluation of transitions. J Appl Behav Anal. 2016 Jun;49(2):359–76. doi: 10.1002/jaba.283. X-126916573
5387 Jeste SS, Geschwind DH. Clinical trials for neurodevelopmental disorders: At a therapeutic frontier. Sci Transl Med. 2016 Jan 13;8(321):321fs1. doi: 10.1126/scitranslmed.aad9874. X-1
5388 Jeste SS, Varcin KJ, Hellemann GS, . Symptom profiles of autism spectrum disorder in tuberous sclerosis complex. Neurology. 2016 Jul 20 doi: 10.1212/wnl.0000000000003002. X-1
5389 Jeyabalan N, Clement JP. SYNGAP1: Mind the Gap. Front Cell Neurosci. 2016;10:32. doi: 10.3389/fncel.2016.00032. X-126912996
5390 Jia F, Cui M, Than MT, . Developmental Defects of Caenorhabditis elegans Lacking Branched-chain alpha-Ketoacid Dehydrogenase Are Mainly Caused by Monomethyl Branched-chain Fatty Acid Deficiency. J Biol Chem. 2016 Feb 5;291(6):2967–73. doi: 10.1074/jbc.M115.676650. X-126683372
5391 Jiang HY, Xu LL, Shao L, . Maternal infection during pregnancy and risk of autism spectrum disorders: A systematic review and meta-analysis. Brain Behav Immun. 2016 Jun 7 doi: 10.1016/j.bbi.2016.06.005. X-1
5392 Jiang HY, Zhou K, Ruan B. Re: Maternal infection during pregnancy, risk of offspring autism, and the role of bacterial denitrification. Brain Behav Immun. 2016 Jun 24 doi: 10.1016/j.bbi.2016.06.012. X-1
5393 Jiang M, Polepalli J, Chen LY, . Conditional ablation of neuroligin-1 in CA1 pyramidal neurons blocks LTP by a cell-autonomous NMDA receptor-independent mechanism. Mol Psychiatry. 2016 May 24 doi: 10.1038/mp.2016.80. X-1
5394 Jin J. JAMA PATIENT PAGE. Screening for Autism Spectrum Disorder. Jama. 2016 Feb 16;315(7):718. doi: 10.1001/jama.2016.0930. X-126881385
5395 Johannessen J, Nærland T, Bloss C, . Parents’ attitudes toward genetic research in autism spectrum disorder. Psychiatric Genetics. 2016;26(2):74–80. doi: http://dx.doi.org/10.1097/YPG.0000000000000121. X-126867185
5396 John TS, Estes AM, Dager SR, . Emerging executive functioning and motor development in infants at high and low risk for autism spectrum disorder. Frontiers in Psychology. 2016;7. X-1
5397 Johnson HL, DeLeon PH. Accessing care for children with special health care needs. Practice Innovations. 2016;1(2):105–16. doi: http://dx.doi.org/10.1037/pri0000019. X-1
5398 Johnson NL, Burkett K, Reinhold J, . Translating Research to Practice for Children With Autism Spectrum Disorder: Part I: Definition, Associated Behaviors, Prevalence, Diagnostic Process, and Interventions. J Pediatr Health Care. 2016 Jan–Feb;30(1):15–26. doi: 10.1016/j.pedhc.2015.09.008. X-126530271
5399 Johnson S, Kochhar P, Hennessy E, . Antecedents of attention-deficit/hyperactivity disorder symptoms in children born extremely preterm. Journal of Developmental and Behavioral Pediatrics. 2016;37(4):285–97. doi: http://dx.doi.org/10.1097/DBP.0000000000000298. X-127096570
5400 Johnson SA, Javurek AB, Painter MS, . Effects of developmental exposure to bisphenol A on spatial navigational learning and memory in rats: A CLARITY-BPA study. Horm Behav. 2016 Apr;80:139–48. doi: 10.1016/j.yhbeh.2015.09.005. X-126436835
5401 Johnston SB, Raines RT. PTENpred: A Designer Protein Impact Predictor for PTEN-related Disorders. J Comput Biol. 2016 Jun 16 doi: 10.1089/cmb.2016.0058. X-1
5402 Jone PN, Ross MM, Bracken JA, . Feasibility and Safety of Using a Fused Echocardiography/Fluoroscopy Imaging System in Patients with Congenital Heart Disease. J Am Soc Echocardiogr. 2016 Jun;29(6):513–21. doi: 10.1016/j.echo.2016.03.014. X-127143284
5403 Jones EJ, Venema K, Earl R, . Reduced engagement with social stimuli in 6-month-old infants with later autism spectrum disorder: a longitudinal prospective study of infants at high familial risk. J Neurodev Disord. 2016;8:7. doi: 10.1186/s11689-016-9139-8. X-126981158
5404 Jones KL, Croen LA, Yoshida CK, . Autism with intellectual disability is associated with increased levels of maternal cytokines and chemokines during gestation. Mol Psychiatry. 2016 May 24 doi: 10.1038/mp.2016.77. X-1
5405 Jones S, Bremer E, Lloyd M. Autism spectrum disorder: family quality of life while waiting for intervention services. Qual Life Res. 2016 Aug 2 doi: 10.1007/s11136-016-1382-7. X-1
5406 Joosten A, Girdler S, Albrecht MA, . Gaze and visual search strategies of children with Asperger syndrome/high functioning autism viewing a magic trick. Developmental Neurorehabilitation. 2016;19(2):95–102. X-124866104
5407 Jorge Garcia A, Polidori C, Nieves-Aldrey JL. Pheomelanin in the secondary sexual characters of male parasitoid wasps (Hymenoptera: Pteromalidae). Arthropod Struct Dev. 2016 May 21 doi: 10.1016/j.asd.2016.05.001. X-1
5408 Joseph RM, O’Shea TM, Allred EN, . Prevalence and associated features of autism spectrum disorder in extremely low gestational age newborns at age 10 years. Autism Res. 2016 May 25 doi: 10.1002/aur.1644. X-1
5409 Joshi G, Wozniak J, Faraone SV, . A Prospective Open-Label Trial of Memantine Hydrochloride for the Treatment of Social Deficits in Intellectually Capable Adults With Autism Spectrum Disorder. J Clin Psychopharmacol. 2016 Jun;36(3):262–71. doi: 10.1097/jcp.0000000000000499. X-127043118
5410 Jowett Hirst ES, Dozier CL, Payne SW. Efficacy of and preference for reinforcement and response cost in token economies. Journal of Applied Behavior Analysis. 2016;49(2):329–45. doi: http://dx.doi.org/10.1002/jaba.294. X-126916640
5411 Julien HM, Reichle J. A comparison of high and low dosages of a component of Milieu teaching strategies for two preschool-age learners with autism spectrum disorder. Language, Speech, and Hearing Services in Schools. 2016;47(1):87–98. doi: http://dx.doi.org/10.1044/2015_LSHSS-15-0035. X-3, X-4
5412 Jull S, Mirenda P. Effects of a staff training program on community instructors’ ability to teach swimming skills to children with autism. Journal of Positive Behavior Interventions. 2016;18(1):29–40. doi: http://dx.doi.org/10.1177/1098300715576797. X-1, X-3, X-4
5413 Julvez J, Mendez M, Fernandez-Barres S, . Maternal Consumption of Seafood in Pregnancy and Child Neuropsychological Development: A Longitudinal Study Based on a Population With High Consumption Levels. Am J Epidemiol. 2016 Feb 1;183(3):169–82. doi: 10.1093/aje/kwv195. X-126740026
5414 Kabir ZD, Lee AS, Rajadhyaksha AM. L-type Ca2+ channels in mood, cognition and addiction: Integrating human and rodent studies with a focus on behavioural endophenotypes. J Physiol. 2016 Feb 23 doi: 10.1113/jp270673. X-1
5415 Kaden E, Kelm ND, Carson RP, . Multi-compartment microscopic diffusion imaging. Neuroimage. 2016 Jun 6 doi: 10.1016/j.neuroimage.2016.06.002. X-1
5416 Kaganovich N. Development of sensitivity to audiovisual temporal asynchrony during midchildhood. Developmental Psychology. 2016;52(2):232–41. doi: http://dx.doi.org/10.1037/dev0000073. X-126569563
5417 Kahle KT, Khanna AR, Duan J, . The KCC2 Cotransporter and Human Epilepsy: Getting Excited About Inhibition. Neuroscientist. 2016 Apr 29 doi: 10.1177/1073858416645087. X-1
5418 Kaiser MD, Yang DY, Voos AC, . Brain Mechanisms for Processing Affective (and Nonaffective) Touch Are Atypical in Autism. Cereb Cortex. 2016 Jun;26(6):2705–14. doi: 10.1093/cercor/bhv125. X-126048952
5419 Kalb LG, Vasa RA, Ballard ED, . Epidemiology of Injury-Related Emergency Department Visits in the US Among Youth with Autism Spectrum Disorder. J Autism Dev Disord. 2016 May 30 doi: 10.1007/s10803-016-2820-7. X-1
5420 Kaldy Z, Giserman I, Carter AS, . The mechanisms underlying the ASD advantage in visual search. Journal of Autism and Developmental Disorders. 2016;46(5):1513–27. doi: http://dx.doi.org/10.1007/s10803-013-1957-x. X-124091470
5421 Kalkman HO, Feuerbach D. Modulatory effects of alpha7 nAChRs on the immune system and its relevance for CNS disorders. Cell Mol Life Sci. 2016 Jul;73(13):2511–30. doi: 10.1007/s00018-016-2175-4. X-126979166
5422 Kalman S, Garbett KA, Janka Z, . Human dermal fibroblasts in psychiatry research. Neuroscience. 2016 Apr 21;320:105–21. doi: 10.1016/j.neuroscience.2016.01.067. X-126855193
5423 Kalueff AV, Stewart AM, Song C, . Neurobiology of rodent self-grooming and its value for translational neuroscience. Nat Rev Neurosci. 2016 Jan;17(1):45–59. doi: 10.1038/nrn.2015.8. X-126675822
5424 Kang CN, Kim CW, Moon JK. The outcomes of instrumented posterolateral lumbar fusion in patients with rheumatoid arthritis. Bone Joint J. 2016 Jan;98-b(1):102–8. doi: 10.1302/0301-620x.98b1.36247. X-126733522
5425 Kang J, Park H, Kim E. IRSp53/BAIAP2 in dendritic spine development, NMDA receptor regulation, and psychiatric disorders. Neuropharmacology. 2016 Jan;100:27–39. doi: 10.1016/j.neuropharm.2015.06.019. X-126275848
5426 Karaminis T, Cicchini GM, Neil L, . Central tendency effects in time interval reproduction in autism. Sci Rep. 2016;6:28570. doi: 10.1038/srep28570. X-127349722
5427 Karhson DS, Golob EJ. Atypical sensory reactivity influences auditory attentional control in adults with autism spectrum disorders. Autism Res. 2016 Jan 18 doi: 10.1002/aur.1593. X-1
5428 Kashima R, Roy S, Ascano M, . Augmented noncanonical BMP type II receptor signaling mediates the synaptic abnormality of fragile X syndrome. Sci Signal. 2016;9(431):ra58. doi: 10.1126/scisignal.aaf6060. X-127273096
5429 Kaskowitz AP, Dendrinos M, Murray PJ, . The Effect of Menstrual Issues on Young Women with Angelman Syndrome. J Pediatr Adolesc Gynecol. 2016 Aug;29(4):348–52. doi: 10.1016/j.jpag.2015.12.004. X-126718530
5430 Katayama K, Yamashita Y, Yatsuga S, . ADHD-like behavior in a patient with hypothalamic hamartoma. Brain & Development. 2016;38(1):145–8. doi: http://dx.doi.org/10.1016/j.braindev.2015.05.011. X-126028458
5431 Kato T, Mandai T, Iwatani S, . Extremely preterm infants small for gestational age are at risk for motor impairment at 3 years corrected age. Brain & Development. 2016;38(2):188–95. doi: http://dx.doi.org/10.1016/j.braindev.2015.07.008. X-126265090
5432 Katz J, d’Albis MA, Boisgontier J, . Similar white matter but opposite grey matter changes in schizophrenia and high-functioning autism. Acta Psychiatr Scand. 2016 Jul;134(1):31–9. doi: 10.1111/acps.12579. X-127105136
5433 Kaufmann FN, Gazal M, Bastos CR, . Curcumin in depressive disorders: An overview of potential mechanisms, preclinical and clinical findings. Eur J Pharmacol. 2016 May 24;784:192–8. doi: 10.1016/j.ejphar.2016.05.026. X-127235294
5434 Kauschke C, van der Beek B, Kamp-Becker I. Narratives of girls and boys with autism spectrum disorders: Gender differences in narrative competence and internal state language. Journal of Autism and Developmental Disorders. 2016;46(3):840–52. doi: http://dx.doi.org/10.1007/s10803-015-2620-5. X-126438638
5435 Kaushik G, Huber DP, Aho K, . Maternal exposure to carbamazepine at environmental concentrations can cross intestinal and placental barriers. Biochem Biophys Res Commun. 2016 May 27;474(2):291–5. doi: 10.1016/j.bbrc.2016.04.088. X-127105911
5436 Kaushik G, Xia Y, Yang L, . Psychoactive pharmaceuticals at environmental concentrations induce in vitro gene expression associated with neurological disorders. BMC Genomics. 2016;17 Suppl 3:435. doi: 10.1186/s12864-016-2784-1. X-127356971
5437 Kawabe K, Kondo S, Matsumoto M, . Developmental quotient to estimate intelligence in autism spectrum disorder. Pediatr Int. 2016 Mar 2 doi: 10.1111/ped.12969. X-1
5438 Kawalekar OU, O’Connor RS, Fraietta JA, . Distinct Signaling of Coreceptors Regulates Specific Metabolism Pathways and Impacts Memory Development in CAR T Cells. Immunity. 2016 Feb 16;44(2):380–90. doi: 10.1016/j.immuni.2016.01.021. X-126885860
5439 Kawamura A, Mylopoulos M, Orsino A, . Promoting the Development of Adaptive Expertise: Exploring a Simulation Model for Sharing a Diagnosis of Autism With Parents. Acad Med. 2016 May 31 doi: 10.1097/acm.0000000000001246. X-1
5440 Kawanai T, Ago Y, Watanabe R, . Prenatal Exposure to Histone Deacetylase Inhibitors Affects Gene Expression of Autism-Related Molecules and Delays Neuronal Maturation. Neurochem Res. 2016 Jun 14 doi: 10.1007/s11064-016-1969-y. X-1
5441 Kay-Raining Bird E, Genesee F, Verhoeven L. Bilingualism in children with developmental disorders: A narrative review. J Commun Disord. 2016 Jul 18 doi: 10.1016/j.jcomdis.2016.07.003. X-1
5442 Kazdoba TM, Leach PT, Yang M, . Translational Mouse Models of Autism: Advancing Toward Pharmacological Therapeutics. Curr Top Behav Neurosci. 2016 Jun 16 doi: 10.1007/7854_2015_5003. X-1
5443 Kazlauskas N, Campolongo M, Lucchina L, . Postnatal behavioral and inflammatory alterations in female pups prenatally exposed to valproic acid. Psychoneuroendocrinology. 2016 Jun 7;72:11–21. doi: 10.1016/j.psyneuen.2016.06.001. X-127337090
5444 Keefer A, Kreiser NL, Singh V, . Intolerance of Uncertainty Predicts Anxiety Outcomes Following CBT in Youth with ASD. J Autism Dev Disord. 2016 Jul 12 doi: 10.1007/s10803-016-2852-z. X-1, X-3
5445 Keehn B, Joseph RM. Exploring what’s missing: What do target absent trials reveal about autism search superiority? Journal of Autism and Developmental Disorders. 2016;46(5):1686–98. doi: http://dx.doi.org/10.1007/s10803-016-2700-1. X-126762114
5446 Keehn B, Nair A, Lincoln AJ, . Under-reactive but easily distracted: An fMRI investigation of attentional capture in autism spectrum disorder. Developmental Cognitive Neuroscience. 2016;17:46–56. doi: http://dx.doi.org/10.1016/j.dcn.2015.12.002. X-126708773
5447 Keen D, Webster A, Ridley G. How well are children with autism spectrum disorder doing academically at school? An overview of the literature. Autism. 2016;20(3):276–94. doi: http://dx.doi.org/10.1177/1362361315580962. X-125948598
5448 Keenan BM, Newman LK, Gray KM, . Parents of Children with ASD Experience More Psychological Distress, Parenting Stress, and Attachment-Related Anxiety. J Autism Dev Disord. 2016 Jun 16 doi: 10.1007/s10803-016-2836-z. X-1
5449 Keil KP, Lein PJ. DNA methylation: a mechanism linking environmental chemical exposures to risk of autism spectrum disorders? Environ Epigenet. 2016 Mar;2(1)doi: 10.1093/eep/dvv012. X-1
5450 Kelley ME, Shillingsburg MA, Bowen CN. Stability of daily preference across multiple individuals. J Appl Behav Anal. 2016 Jun;49(2):394–8. doi: 10.1002/jaba.288. X-126816192
5451 Kelly MP, Zebala LP, Kim HJ, . Effectiveness of preoperative autologous blood donation for protection against allogeneic blood exposure in adult spinal deformity surgeries: a propensity-matched cohort analysis. J Neurosurg Spine. 2016 Jan;24(1):124–30. doi: 10.3171/2015.4.spine141329. X-126407086
5452 Kennedy AJ, Rahn EJ, Paulukaitis BS, . Tcf4 Regulates Synaptic Plasticity, DNA Methylation, and Memory Function. Cell Rep. 2016 Aug 24 doi: 10.1016/j.celrep.2016.08.004. X-1
5453 Kennedy M, Kreppner J, Knights N, . Early severe institutional deprivation is associated with a persistent variant of adult attention-deficit/hyperactivity disorder: clinical presentation, developmental continuities and life circumstances in the English and Romanian Adoptees study. J Child Psychol Psychiatry. 2016 Jun 6 doi: 10.1111/jcpp.12576. X-1
5454 Kentner AC, Khoury A, Lima Queiroz E, . Environmental enrichment rescues the effects of early life inflammation on markers of synaptic transmission and plasticity. Brain Behav Immun. 2016 Mar 18 doi: 10.1016/j.bbi.2016.03.013. X-1
5455 Kerns KA, Macoun S, MacSween J, . Attention and Working Memory Training: A Feasibility Study in Children with Neurodevelopmental Disorders. Appl Neuropsychol Child. 2016 Apr 6:1–18. doi: 10.1080/21622965.2015.1109513. X-127551909
5456 Kerr DJ, Marsillo A, Guariglia SR, . Aberrant hippocampal Atp8a1 levels are associated with altered synaptic strength, electrical activity, and autistic-like behavior. Biochim Biophys Acta. 2016 Jun 7;1862(9):1755–65. doi: 10.1016/j.bbadis.2016.06.005. X-127287255
5457 Kessler D, Angstadt M, Sripada C. Growth charting of brain connectivity networks and the identification of attention impairment in youth. JAMA Psychiatry. 2016;73(5):481–9. doi: http://dx.doi.org/10.1001/jamapsychiatry.2016.0088. X-127076193
5458 Ketcheson L, Hauck J, Ulrich D. The effects of an early motor skill intervention on motor skills, levels of physical activity, and socialization in young children with autism spectrum disorder: A pilot study. Autism. 2016 Jun 26 doi: 10.1177/1362361316650611. X-1
5459 Key AP, Yoder PJ, Stone WL. Consonant differentiation mediates the discrepancy between non-verbal and verbal abilities in children with ASD. Journal of Intellectual Disability Research. 2016;60(5):478–90. doi: http://dx.doi.org/10.1111/jir.12286. X-127120990
5460 Khadmaoui A, Gómez C, Poza J, . MEG analysis of neural interactions in attention-deficit/hyperactivity disorder. Computational Intelligence and Neuroscience. 2016;2016 doi: http://dx.doi.org/10.1155/2016/8450241. X-1
5461 Khemir S, Halayem S, Azzouz H, . Autism in phenylketonuria patients: From clinical presentation to molecular defects. Journal of Child Neurology. 2016;31(7):843–9. doi: http://dx.doi.org/10.1177/0883073815623636. X-126759449
5462 Khemka I, Hickson L, Mallory SB. Evaluation of a Decision-Making Curriculum for Teaching Adolescents with Disabilities to Resist Negative Peer Pressure. J Autism Dev Disord. 2016 Jul;46(7):2372–84. doi: 10.1007/s10803-016-2770-0. X-126993636
5463 Kiely B, Migdal TR, Vettam S, . Prevalence and Correlates of Elopement in a Nationally Representative Sample of Children with Developmental Disabilities in the United States. PLoS One. 2016;11(2):e0148337. doi: 10.1371/journal.pone.0148337. X-126845701
5464 Kijima Y, Akagi T, Takaya Y, . Deficient Surrounding Rims in Patients Undergoing Transcatheter Atrial Septal Defect Closure. J Am Soc Echocardiogr. 2016 May 25 doi: 10.1016/j.echo.2016.04.010. X-1
5465 Kilincaslan A, Mutluer TD, Pasabeyoglu B, . Effects of Atomoxetine in Individuals with Attention-Deficit/Hyperactivity Disorder and Low-Functioning Autism Spectrum Disorder. J Child Adolesc Psychopharmacol. 2016 May 26 doi: 10.1089/cap.2015.0179. X-2, X-3
5466 Kim H, Carlson AG, Curby TW, . Relations among motor, social, and cognitive skills in pre-kindergarten children with developmental disabilities. Research in Developmental Disabilities. 2016;53–54:43–60. doi: http://dx.doi.org/10.1016/j.ridd.2016.01.016. X-1
5467 Kim H, Lim CS, Kaang BK. Neuronal mechanisms and circuits underlying repetitive behaviors in mouse models of autism spectrum disorder. Behav Brain Funct. 2016;12(1):3. doi: 10.1186/s12993-016-0087-y. X-126790724
5468 Kim HJ, Cho MH, Shim WH, . Deficient autophagy in microglia impairs synaptic pruning and causes social behavioral defects. Mol Psychiatry. 2016 Jul 12 doi: 10.1038/mp.2016.103. X-1
5469 Kim HJ, Iyer S, Zebala LP, . Perioperative Neurologic Complications in Adult Spinal Deformity Surgery: Incidence and Risk factors in 564 Patients. Spine (Phila Pa 1976). 2016 Jul 7 doi: 10.1097/brs.0000000000001774. X-1
5470 Kim HY, Korade Z, Tallman KA, . Inhibitors of 7-Dehydrocholesterol Reductase: Screening of a Collection of Pharmacologically Active Compounds in Neuro2a Cells. Chem Res Toxicol. 2016 May 16;29(5):892–900. doi: 10.1021/acs.chemrestox.6b00054. X-127097157
5471 Kim I, Ekas NV, Hock R. Associations between child behavior problems, family management, and depressive symptoms for mothers of children with autism spectrum disorder. Research in Autism Spectrum Disorders. 2016;26:80–90. doi: http://dx.doi.org/10.1016/j.rasd.2016.03.009. X-1
5472 Kim JM, Eom TH. The Pseudosubarachnoid Sign: Clinical Implications of Subarachnoid Hemorrhage Misdiagnosis. Pediatr Emerg Care. 2016 May 12 doi: 10.1097/pec.0000000000000746. X-1
5473 Kim JY, Ryu DS, Paik HK, . Paraspinal muscle, facet joint, and disc problems: risk factors for adjacent segment degeneration after lumbar fusion. Spine J. 2016 Mar 9 doi: 10.1016/j.spinee.2016.03.010. X-1
5474 Kim S, Boylan K. Effectiveness of Antidepressant Medications for Symptoms of Irritability and Disruptive Behaviors in Children and Adolescents. J Child Adolesc Psychopharmacol. 2016 Aug 2 doi: 10.1089/cap.2015.0127. X-1
5475 Kim SH, Kim YS, Koh YJ, . Often Asked but Rarely Answered: Can Asians Meet DSM-5/ICD-10 Autism Spectrum Disorder Criteria? J Child Adolesc Psychopharmacol. 2016 Jun 17 doi: 10.1089/cap.2016.0021. X-1
5476 Kim SH, Lyu I, Fonov VS, . Development of cortical shape in the human brain from 6 to 24 months of age via a novel measure of shape complexity. NeuroImage. 2016;135:163–76. doi: http://dx.doi.org/10.1016/j.neuroimage.2016.04.053. X-127150231
5477 Kim SH, Macari S, Koller J, . Examining the phenotypic heterogeneity of early autism spectrum disorder: Subtypes and short-term outcomes. Journal of Child Psychology and Psychiatry. 2016;57(1):93–102. doi: http://dx.doi.org/10.1111/jcpp.12448. X-1
5478 Kim SY, De Vries RG, Peteet JR. Euthanasia and Assisted Suicide of Patients With Psychiatric Disorders in the Netherlands 2011 to 2014. JAMA Psychiatry. 2016 Apr;73(4):362–8. doi: 10.1001/jamapsychiatry.2015.2887. X-126864709
5479 Kimura M, Yamazaki Y. Physical punishment, mental health and sense of coherence among parents of children with intellectual disability in Japan. Journal of Applied Research in Intellectual Disabilities. 2016;29(5):455–67. doi: http://dx.doi.org/10.1111/jar.12198. X-126011120
5480 King BH. Assessing Risk of Autism Spectrum Disorder in Children After Antidepressant Use During Pregnancy. JAMA Pediatr. 2016 Feb;170(2):111–2. doi: 10.1001/jamapediatrics.2015.3493. X-126660503
5481 King LB, Koch M, Murphy KR, . Neurofibromin Loss of Function Drives Excessive Grooming in Drosophila. G3 (Bethesda). 2016;6(4):1083–93. doi: 10.1534/g3.115.026484. X-126896440
5482 King LB, Walum H, Inoue K, . Variation in the Oxytocin Receptor Gene Predicts Brain Region-Specific Expression and Social Attachment. Biol Psychiatry. 2016 Jul 15;80(2):160–9. doi: 10.1016/j.biopsych.2015.12.008. X-126893121
5483 Kinnear SH, Link BG, Ballan MS, . Understanding the experience of stigma for parents of children with autism spectrum disorder and the role stigma plays in families’ lives. Journal of Autism and Developmental Disorders. 2016;46(3):942–53. doi: http://dx.doi.org/10.1007/s10803-015-2637-9. X-126659549
5484 Kirby AV, Boyd BA, Williams KL, . Sensory and repetitive behaviors among children with autism spectrum disorder at home. Autism. 2016 Apr 18 doi: 10.1177/1362361316632710. X-1
5485 Kirby AV, Little LM, Schultz B, . Development and Pilot of the Caregiver Strategies Inventory. Am J Occup Ther. 2016 Jul–Aug;70(4):7004360010p1–6. doi: 10.5014/ajot.2016.019901. X-1
5486 Kirkovski M, Rogasch NC, Saeki T, . Single Pulse Transcranial Magnetic Stimulation-Electroencephalogram Reveals No Electrophysiological Abnormality in Adults with High-Functioning Autism Spectrum Disorder. J Child Adolesc Psychopharmacol. 2016 Jun 10 doi: 10.1089/cap.2015.0181. X-1
5487 Kister T, Dahnert I, Lurz P. Fatal Erosion Atrial Septal Defect Device. Catheter Cardiovasc Interv. 2016 Apr;87(5):951–4. doi: 10.1002/ccd.26219. X-126354498
5488 Kitazoe N, Fujita N, Izumoto Y, . Whether the Autism Spectrum Quotient consists of two different subgroups? Cluster analysis of the Autism Spectrum Quotient in general population. Autism. 2016 Apr 30 doi: 10.1177/1362361316638787. X-1
5489 Klein N, Kemper KJ. Integrative Approaches to Caring for Children with Autism. Curr Probl Pediatr Adolesc Health Care. 2016 Jun;46(6):195–201. doi: 10.1016/j.cppeds.2015.12.004. X-1, X-226776326
5490 Klionsky DJ, Abdelmohsen K, Abe A, . Guidelines for the use and interpretation of assays for monitoring autophagy (3rd edition). Autophagy. 2016;12(1):1–222. doi: 10.1080/15548627.2015.1100356. X-126799652
5491 Kloo D, Kain W. The direct way may not be the best way: Children with ADHD and their understanding of self-presentation in social interactions. European Journal of Developmental Psychology. 2016;13(1):40–51. doi: http://dx.doi.org/10.1080/17405629.2015.1051960. X-127081391
5492 Knight AM, Xie M, Mandell DS. Disparities in Psychiatric Diagnosis and Treatment for Youth with Systemic Lupus Erythematosus: Analysis of a National US Medicaid Sample. J Rheumatol. 2016 Jul;43(7):1427–33. doi: 10.3899/jrheum.150967. X-127134262
5493 Ko C, Kim N, Kim E, . The effect of epilepsy on autistic symptom severity assessed by the Social Responsiveness Scale in children with autism spectrum disorder. Behavioral and Brain Functions. 2016;12 doi: http://dx.doi.org/10.1186/s12993-016-0105-0. X-127048243
5494 Kodak T, Campbell V, Bergmann S, . Examination of efficacious, efficient, and socially valid error-correction procedures to teach sight words and prepositions to children with autism spectrum disorder. J Appl Behav Anal. 2016 May 6 doi: 10.1002/jaba.310. X-1
5495 Koehne S, Behrends A, Fairhurst MT, . Fostering Social Cognition through an Imitation- and Synchronization-Based Dance/Movement Intervention in Adults with Autism Spectrum Disorder: A Controlled Proof-of-Concept Study. Psychother Psychosom. 2016;85(1):27–35. doi: 10.1159/000441111. X-126609704
5496 Koks N, Ghassabian A, Greaves-Lord K, . Maternal C-Reactive Protein Concentration in Early Pregnancy and Child Autistic Traits in the General Population. Paediatr Perinat Epidemiol. 2016 Mar;30(2):181–9. doi: 10.1111/ppe.12261. X-126860445
5497 Kondolot M, Özmert EN, Öztop DB, . The modified checklist for autism in Turkish toddlers: A different cultural adaptation sample. Research in Autism Spectrum Disorders. 2016;21:121–7. doi: http://dx.doi.org/10.1016/j.rasd.2015.10.006. X-1
5498 Konopka G, Roberts TF. Animal Models of Speech and Vocal Communication Deficits Associated With Psychiatric Disorders. Biol Psychiatry. 2016 Jan 1;79(1):53–61. doi: 10.1016/j.biopsych.2015.07.001. X-126232298
5499 Konrad M, Drosselmeyer J, Kostev K. Referral for occupational therapy after diagnosis of developmental disorder by German child psychiatrists. Early Child Development and Care. 2016;186(6):959–70. doi: http://dx.doi.org/10.1080/03004430.2015.1070262. X-1
5500 Koolschijn PC, Geurts HM. Gray Matter Characteristics in Mid and Old Aged Adults with ASD. J Autism Dev Disord. 2016 May 13 doi: 10.1007/s10803-016-2810-9. X-1
5501 Koren’ EV, Kupriyanova TA, Drobinskaya AO, . Effects of mental disorders in children on parents in the context of differentiated approaches to psychosocial interventions in pediatric psychiatry. Neuroscience and Behavioral Physiology. 2016;46(4):394–9. doi: http://dx.doi.org/10.1007/s11055-016-0248-3. X-1
5502 Korhonen V, Werner S. Autistic traits and attention to speech: Evidence from typically developing individuals. Logoped Phoniatr Vocol. 2016 May 23:1–7. doi: 10.1080/14015439.2016.1186731. X-1
5503 Korkiakangas T, Dindar K, Laitila A, . The Sally-Anne test: an interactional analysis of a dyadic assessment. Int J Lang Commun Disord. 2016 May 17 doi: 10.1111/1460-6984.12240. X-1
5504 Kos A, Olde Loohuis N, Meinhardt J, . MicroRNA-181 promotes synaptogenesis and attenuates axonal outgrowth in cortical neurons. Cell Mol Life Sci. 2016 Mar 26 doi: 10.1007/s00018-016-2179-0. X-1
5505 Kosaka H, Okamoto Y, Munesue T, . Oxytocin efficacy is modulated by dosage and oxytocin receptor genotype in young adults with high-functioning autism: a 24-week randomized clinical trial. Transl Psychiatry. 2016;6(8):e872. doi: 10.1038/tp.2016.152. X-127552585
5506 Koshiba M, Karino G, Mimura K, . Psycho-Cognitive Intervention for ASD from Cross-Species Behavioral Analyses of Infants, Chicks and Common Marmosets. CNS Neurol Disord Drug Targets. 2016;15(5):578–86. X-127071788
5507 Koski S, Gabriels RL, Beresford C. Interventions for paediatric surgery patients with comorbid autism spectrum disorder: a systematic literature review. Arch Dis Child. 2016 May 25 doi: 10.1136/archdischild-2016-310814. X-1
5508 Kossyvaki L, Jones G, Guldberg K. Training teaching staff to facilitate spontaneous communication in children with autism: Adult Interactive Style Intervention (AISI). Journal of Research in Special Educational Needs. 2016;16(3):156–68. doi: http://dx.doi.org/10.1111/1471-3802.12068. X-3, X-4
5509 Kossyvaki L, Papoudi D. A review of play interventions for children with autism at school. International Journal of Disability, Development and Education. 2016;63(1):45–63. doi: http://dx.doi.org/10.1080/1034912X.2015.1111303. X-1, X-2
5510 Kot M, Buning J, Jankowska W, . Development of ovary structures in the last larval and adult stages of psyllids (Insecta, Hemiptera, Sternorrhyncha: Psylloidea). Arthropod Struct Dev. 2016 May 6 doi: 10.1016/j.asd.2016.04.004. X-1
5511 Kovac M, Mosner M, Miller S, . Experience sampling of positive affect in adolescents with autism: Feasibility and preliminary findings. Research in Autism Spectrum Disorders. 2016;29–30:57–65. doi: http://dx.doi.org/10.1016/j.rasd.2016.06.003. X-1
5512 Kovarski K, Thillay A, Houy-Durand E, . Brief Report: Early VEPs to Pattern-Reversal in Adolescents and Adults with Autism. J Autism Dev Disord. 2016 Jul 30 doi: 10.1007/s10803-016-2880-8. X-1
5513 Kover ST, Edmunds SR, Ellis Weismer S. Brief Report: Ages of Language Milestones as Predictors of Developmental Trajectories in Young Children with Autism Spectrum Disorder. J Autism Dev Disord. 2016 Jul;46(7):2501–7. doi: 10.1007/s10803-016-2756-y. X-126936159
5514 Kozol RA, Abrams AJ, James DM, . Function Over Form: Modeling Groups of Inherited Neurological Conditions in Zebrafish. Front Mol Neurosci. 2016;9:55. doi: 10.3389/fnmol.2016.00055. X-127458342
5515 Krahe TE, Filgueiras CC, Medina AE. Effects of developmental alcohol and valproic acid exposure on play behavior of ferrets. Int J Dev Neurosci. 2016 May 18;52:75–81. doi: 10.1016/j.ijdevneu.2016.03.007. X-127208641
5516 Krakovich TM, McGrew JH, Yu Y, . Stress in Parents of Children with Autism Spectrum Disorder: An Exploration of Demands and Resources. J Autism Dev Disord. 2016 Jun;46(6):2042–53. doi: 10.1007/s10803-016-2728-2. X-126883644
5517 Krakowiak P, Walker CK, Tancredi D, . Autism-specific maternal anti-fetal brain autoantibodies are associated with metabolic conditions. Autism Res. 2016 Jun 17 doi: 10.1002/aur.1657. X-1
5518 Kramer JM, Liljenquist K, Coster WJ. Validity, reliability, and usability of the Pediatric Evaluation of Disability Inventory-Computer Adaptive Test for autism spectrum disorders. Dev Med Child Neurol. 2016 Mar;58(3):255–61. doi: 10.1111/dmcn.12837. X-126104112
5519 Kranz TM, Kopp M, Waltes R, . Meta-analysis and association of two common polymorphisms of the human oxytocin receptor gene in autism spectrum disorder. Autism Res. 2016 Jan 20 doi: 10.1002/aur.1597. X-1
5520 Kreider CM, Bendixen RM, Young ME, . Social networks and participation with others for youth with learning, attention, and autism spectrum disorders. Can J Occup Ther. 2016 Feb;83(1):14–26. doi: 10.1177/0008417415583107. X-126755040
5521 Kronenberg LM, Goossens PJ, van Busschbach JT, . Burden and Expressed Emotion of Caregivers in Cases of Adult Substance Use Disorder with and Without Attention Deficit/Hyperactivity Disorder or Autism Spectrum Disorder. Int J Ment Health Addict. 2016;14:49–63. doi: 10.1007/s11469-015-9567-9. X-126798327
5522 Krstovska-Guerrero I, Jones EA. Social-communication intervention for toddlers with Autism Spectrum Disorder: Eye gaze in the context of requesting and joint attention. Journal of Developmental and Physical Disabilities. 2016;28(2):289–316. doi: http://dx.doi.org/10.1007/s10882-015-9466-9. X-3, X-4
5523 Krystal JH, Abi-Dargham A, Akbarian S, . Constance E. Lieber, Theodore R. Stanley, and the Enduring Impact of Philanthropy on Psychiatry Research. Biol Psychiatry. 2016 Jul 15;80(2):84–6. doi: 10.1016/j.biopsych.2016.05.004. X-127346079
5524 Krystal JH, Abi-Dargham A, Barch DM, . Biological Psychiatry and Biological Psychiatry: Cognitive Neuroscience and Neuroimaging Adopt Neuroscience-Based Nomenclature. Biol Psychiatry. 2016 Jul 1;80(1):2–3. doi: 10.1016/j.biopsych.2016.03.2103. X-127312230
5525 Kuiper MW, Verhoeven EW, Geurts HM. The role of interstimulus interval and “Stimulus-type” in prepotent response inhibition abilities in people with ASD: A quantitative and qualitative review. Autism Res. 2016 Apr 19 doi: 10.1002/aur.1631. X-1
5526 Kulakova E, Nieuwland MS. Pragmatic skills predict online counterfactual comprehension: Evidence from the N400. Cogn Affect Behav Neurosci. 2016 May 9 doi: 10.3758/s13415-016-0433-4. X-1
5527 Kumar A, Juneja M, Mishra D. Prevalence of autism spectrum disorders in siblings of Indian children with autism spectrum disorders. Journal of Child Neurology. 2016;31(7):873–8. doi: http://dx.doi.org/10.1177/0883073815624764. X-126733506
5528 Kumar H, Sharma B. Memantine ameliorates autistic behavior, biochemistry & blood brain barrier impairments in rats. Brain Res Bull. 2016 Mar 23;124:27–39. doi: 10.1016/j.brainresbull.2016.03.013. X-127034117
5529 Kumazaki H, Muramatsu T, Fujisawa TX, . Assessment of olfactory detection thresholds in children with autism spectrum disorders using a pulse ejection system. Mol Autism. 2016;7:6. doi: 10.1186/s13229-016-0071-2. X-126788283
5530 Kung KT, Constantinescu M, Browne WV, . No relationship between early postnatal testosterone concentrations and autistic traits in 18 to 30-month-old children. Mol Autism. 2016;7:15. doi: 10.1186/s13229-016-0078-8. X-126893820
5531 Kurita T, Kikuchi M, Yoshimura Y, . Atypical Bilateral Brain Synchronization in the Early Stage of Human Voice Auditory Processing in Young Children with Autism. PLoS One. 2016;11(4):e0153077. doi: 10.1371/journal.pone.0153077. X-127074011
5532 Kuroda T, Cancado CR, Podlesnik CA. Resistance to change and resurgence in humans engaging in a computer task. Behav Processes. 2016 Apr;125:1–5. doi: 10.1016/j.beproc.2016.01.010. X-126836390
5533 Kurth JA, Mastergeorge AM, Paschall K. Economic and demographic factors impacting placement of students with autism. Education and Training in Autism and Developmental Disabilities. 2016;51(1):3–12. X-1
5534 Kwon M-K, Setoodehnia M, Baek J, . The development of visual search in infancy: Attention to faces versus salience. Developmental Psychology. 2016;52(4):537–55. doi: http://dx.doi.org/10.1037/dev0000080. X-126866728
5535 Kyzar EJ, Stewart AM, Kalueff AV. Effects of LSD on grooming behavior in serotonin transporter heterozygous (Sert(+)/(−)) mice. Behav Brain Res. 2016 Jan 1;296:47–52. doi: 10.1016/j.bbr.2015.08.018. X-126340513
5536 Ladd-Acosta C, Shu C, Lee BK, . Presence of an epigenetic signature of prenatal cigarette smoke exposure in childhood. Environ Res. 2016 Jan;144(Pt A):139–48. doi: 10.1016/j.envres.2015.11.014. X-126610292
5537 Lai JK, Lerch JP, Doering LC, . Regional brain volumes changes in adult male FMR1-KO mouse on the FVB strain. Neuroscience. 2016 Mar 24;318:12–21. doi: 10.1016/j.neuroscience.2016.01.021. X-126794591
5538 Lambert A, Tessier S, Rochette A-C, . Poor sleep affects daytime functioning in typically developing and autistic children not complaining of sleep problems: A questionnaire-based and polysomnographic study. Research in Autism Spectrum Disorders. 2016;23:94–106. doi: http://dx.doi.org/10.1016/j.rasd.2015.11.010. X-1
5539 Lamberti M, Siracusano R, Italiano D, . Head-to-Head Comparison of Aripiprazole and Risperidone in the Treatment of ADHD Symptoms in Children with Autistic Spectrum Disorder and ADHD: A Pilot, Open-Label, Randomized Controlled Study. Paediatr Drugs. 2016 Aug;18(4):319–29. doi: 10.1007/s40272-016-0183-3.27278054
5540 Landa R, Hanley GP. An evaluation of multiple-schedule variations to reduce high-rate requests in the picture exchange communication system. J Appl Behav Anal. 2016 Jun;49(2):388–93. doi: 10.1002/jaba.285. X-1, X-426814152
5541 Lane JD, Ledford JR. A review of interventions designed to increase sharing behaviors in children with social delays or deficits. Journal of Behavioral Education. 2016;25(1):69–94. doi: http://dx.doi.org/10.1007/s10864-015-9235-y. X-1, X-2
5542 Lane JD, Lieberman-Betz R, Gast DL. An analysis of naturalistic interventions for increasing spontaneous expressive language in children with autism spectrum disorder. The Journal of Special Education. 2016;50(1):49–61. doi: http://dx.doi.org/10.1177/0022466915614837. X-2
5543 Lane JD, Shepley C, Lieberman-Betz R. Promoting Expressive Language in Young Children with or At-Risk for Autism Spectrum Disorder in a Preschool Classroom. J Autism Dev Disord. 2016 Jul 15 doi: 10.1007/s10803-016-2856-8. X-3, X-4
5544 Lange H, Buse J, Bender S, . Accident proneness in children and adolescents affected by ADHD and the impact of medication. Journal of Attention Disorders. 2016;20(6):501–9. doi: http://dx.doi.org/10.1177/1087054713518237. X-124470540
5545 Langh U, Hammar M, Klintwall L, . Allegiance and knowledge levels of professionals working with early intensive behavioural intervention in autism. Early Interv Psychiatry. 2016 Apr 6 doi: 10.1111/eip.12335. X-1
5546 Lanovaz MJ, Rapp JT, Maciw I, . Preliminary effects of parent-implemented behavioural interventions for stereotypy. Dev Neurorehabil. 2016 Jun;19(3):193–6. doi: 10.3109/17518423.2014.986821. X-3, X-425549178
5547 Laskowski RA, Tyagi N, Johnson D, . Integrating population variation and protein structural analysis to improve clinical interpretation of missense variation: application to the WD40 domain. Hum Mol Genet. 2016 Mar 1;25(5):927–35. doi: 10.1093/hmg/ddv625. X-126740553
5548 Latifi R, Gunn JK, Bakiu E, . Access to Specialized Care Through Telemedicine in Limited-Resource Country: Initial 1,065 Teleconsultations in Albania. Telemed J E Health. 2016 May 24 doi: 10.1089/tmj.2016.0050. X-1
5549 Lau WYP, Peterson CC, Attwood T, . Parents on the autism continuum: Links with parenting efficacy. Research in Autism Spectrum Disorders. 2016;26:57–64. doi: http://dx.doi.org/10.1016/j.rasd.2016.02.007. X-1
5550 Lawson LM, Foster L. Sensory Patterns, Obesity, and Physical Activity Participation of Children With Autism Spectrum Disorder. Am J Occup Ther. 2016 Sep–Oct;70(5):7005180070p1–8. doi: 10.5014/ajot.2016.021535. X-1
5551 Lawson SK, Gray AC, Woehrle NS. Effects of oxytocin on serotonin 1B agonist-induced autism-like behavior in mice. Behav Brain Res. 2016 Jul 18;314:52–64. doi: 10.1016/j.bbr.2016.07.027. X-127439030
5552 Lazaro CP, Ponde MP, Rodrigues LE. Opioid peptides and gastrointestinal symptoms in autism spectrum disorders. Rev Bras Psiquiatr. 2016 Jun 14:0. doi: 10.1590/1516-4446-2015-1777. X-1
5553 Lazenby DC, Sideridis GD, Huntington N, . Language differences at 12 months in infants who develop autism spectrum disorder. Journal of Autism and Developmental Disorders. 2016;46(3):899–909. doi: http://dx.doi.org/10.1007/s10803-015-2632-1. X-126476738
5554 Leach EL, van Karnebeek CD, Townsend KN, . Episodic ataxia associated with a de novo SCN2A mutation. Eur J Paediatr Neurol. 2016 Jun 14 doi: 10.1016/j.ejpn.2016.05.020. X-1
5555 Leaf JA, Leaf JB, Milne C, . The effects of the cool versus not cool procedure to teach social game play to individuals diagnosed with autism spectrum disorder. Behavior Analysis in Practice. 2016;9(1):34–49. doi: http://dx.doi.org/10.1007/s40617-016-0112-5. X-3, X-427606237
5556 Leaf JB, Leaf JA, Alcalay A, . Comparison of most-to-least prompting to flexible prompt fading for children with autism spectrum disorder. Exceptionality. 2016;24(2):109–22. doi: http://dx.doi.org/10.1080/09362835.2015.1064419. X-1, X-4
5557 Leaf JB, Mitchell E, Townley-Cochran D, . Comparing Social Stories™ to cool versus not cool. Education & Treatment of Children. 2016;39(2):173–86. doi: http://dx.doi.org/10.1353/etc.2016.0006. X-1, X-3, X-4
5558 Leaf JB, Oppenheim-Leaf ML, Townley-Cochran D, . Changing preference from tangible to social activities through an observation procedure. Journal of Applied Behavior Analysis. 2016;49(1):49–57. doi: http://dx.doi.org/10.1002/jaba.276. X-126660202
5559 Leaf JB, Taubman M, Milne C, . Teaching social communication skills using a cool versus not cool procedure plus role-playing and a social skills taxonomy. Education & Treatment of Children. 2016;39(1):44–63. X-3, X-4
5560 Leaf JB, Townley-Cochran D, Mitchell E, . Evaluation of multiple-alternative prompts during tact training. J Appl Behav Anal. 2016 Jun;49(2):399–404. doi: 10.1002/jaba.289. X-426792578
5561 Leaf JB, Townley-Cochran D, Mitchell E, . Evaluation of multiple-alternative prompts during tact training. Journal of Applied Behavior Analysis. 2016;49(2):399–404. doi: http://dx.doi.org/10.1002/jaba.289. X-426792578
5562 LeBarton ES, Iverson JM. Associations between gross motor and communicative development in at-risk infants. Infant Behav Dev. 2016 Jun 14;44:59–67. doi: 10.1016/j.infbeh.2016.05.003. X-127314943
5563 LeBlanc JJ, Nelson CA. Deletion and duplication of 16p11.2 are associated with opposing effects on visual evoked potential amplitude. Mol Autism. 2016;7:30. doi: 10.1186/s13229-016-0095-7. X-127354901
5564 Lechpammer M, Tran YP, Wintermark P, . Upregulation of cystathione beta-synthase and p70S6K/S6 in neonatal hypoxic ischemic brain injury. Brain Pathol. 2016 Jul 28 doi: 10.1111/bpa.12421. X-1
5565 Lee B. What are the benefits of phenotype analyses to special education? Am J Med Genet B Neuropsychiatr Genet. 2016 Mar;171b(2):301. doi: 10.1002/ajmg.b.32405. X-126614532
5566 Lee C-Y, Su C-T, Chiang F-M, . Developing a short form of the Psychoeducational Profile-Third Edition for children with autism spectrum disorder. Research in Autism Spectrum Disorders. 2016;21:37–50. doi: http://dx.doi.org/10.1016/j.rasd.2015.09.008. X-1
5567 Lee HJ, Dreyfus C, DiCicco-Bloom E. Valproic acid stimulates proliferation of glial precursors during cortical gliogenesis in developing rat. Dev Neurobiol. 2016 Jul;76(7):780–98. doi: 10.1002/dneu.22359. X-126505176
5568 Lee JA, Damianov A, Lin CH, . Cytoplasmic Rbfox1 Regulates the Expression of Synaptic and Autism-Related Genes. Neuron. 2016 Jan 6;89(1):113–28. doi: 10.1016/j.neuron.2015.11.025. X-126687839
5569 Lee JH, Kim KT, Lee SH, . Overcorrection of lumbar lordosis for adult spinal deformity with sagittal imbalance: comparison of radiographic outcomes between overcorrection and undercorrection. Eur Spine J. 2016 Feb 16 doi: 10.1007/s00586-016-4441-4. X-1
5570 Lee K, Goodman L, Fourie C, . AMPA Receptors as Therapeutic Targets for Neurological Disorders. Adv Protein Chem Struct Biol. 2016;103:203–61. doi: 10.1016/bs.apcsb.2015.10.004. X-126920691
5571 Lee K, Lambert H, Wittich W, . The use of movement-based interventions with children diagnosed with autism for psychosocial outcomes—a scoping review. Research in Autism Spectrum Disorders. 2016 2016-06-30;24:52–67. doi: 10.1016/j.newideapsych.2010.03.004. http://dx.doi.org/10.1016/j.rasd.2015.12.011; 2016-08981-007. X-1, X-2
5572 Lee KYS, Crooke PJ, Lui ALY, . The outcome of a social cognitive training for mainstream adolescents with social communication deficits in a Chinese community. International Journal of Disability, Development and Education. 2016;63(2):201–23. doi: http://dx.doi.org/10.1080/1034912X.2015.1065960. X-1, X-3
5573 Lee SM, Kim BK, Kim TW, . Music application alleviates short-term memory impairments through increasing cell proliferation in the hippocampus of valproic acid-induced autistic rat pups. J Exerc Rehabil. 2016 Jun;12(3):148–55. doi: 10.12965/jer.1632638.319. X-127419108
5574 Lee Y-C, Chan P-C, Lin S-K, . Correlation patterns between pretend play and playfulness in children with autism spectrum disorder, developmental delay, and typical development. Research in Autism Spectrum Disorders. 2016;24:29–38. doi: http://dx.doi.org/10.1016/j.rasd.2016.01.006. X-1
5575 Lee Y-c, Yang H-J, Chen VC-h, . Meta-analysis of quality of life in children and adolescents with ADHD: By both parent proxy-report and child self-report using PedsQLTM. Research in Developmental Disabilities. 2016;51–52:160–72. doi: http://dx.doi.org/10.1016/j.ridd.2015.11.009. X-1
5576 Lee YH, Lenhart PD, Lambert SR. Cataract secondary to self-inflicted blunt trauma in children with autism spectrum disorder. J aapos. 2016 May 17 doi: 10.1016/j.jaapos.2016.02.013. X-1
5577 Leffa DD, Daumann F, Damiani AP, . DNA damage after chronic oxytocin administration in rats: a safety yellow light? Metab Brain Dis. 2016 Aug 3 doi: 10.1007/s11011-016-9885-z. X-1
5578 Lehnhardt FG, Falter CM, Gawronski A, . Sex-Related Cognitive Profile in Autism Spectrum Disorders Diagnosed Late in Life: Implications for the Female Autistic Phenotype. J Autism Dev Disord. 2016 Jan;46(1):139–54. doi: 10.1007/s10803-015-2558-7. X-126319250
5579 Lehti V, Chudal R, Suominen A, . Association between immigrant background and ADHD: A nationwide population-based case–control study. Journal of Child Psychology and Psychiatry. 2016;57(8):967–75. doi: http://dx.doi.org/10.1111/jcpp.12570. X-127133554
5580 Leigh JP, Grosse SD, Cassady D, . Spending by California’s Department of Developmental Services for Persons with Autism across Demographic and Expenditure Categories. PLoS One. 2016;11(3):e0151970. doi: 10.1371/journal.pone.0151970. X-127015098
5581 Lense MD, Dykens EM. Beat perception and sociability: Evidence from Williams syndrome. Frontiers in Psychology. 2016;7. X-1
5582 Leon Guerrero CR, Pathak S, Grange DK, . Neurologic and neuroimaging manifestations of Cantu syndrome: A case series. Neurology. 2016 Jun 17 doi: 10.1212/wnl.0000000000002861. X-1
5583 Leon Guerrero CR, Pathak S, Grange DK, . Neurologic and neuroimaging manifestations of Cantú syndrome: A case series. Neurology. 2016;87(3):270–6. doi: http://dx.doi.org/10.1212/WNL.0000000000002861. X-127316244
5584 Leone E, Dorstyn D, Ward L. Defining resilience in families living with neurodevelopmental disorder: A preliminary examination of Walsh’s framework. Journal of Developmental and Physical Disabilities. 2016;28(4):595–608. doi: http://dx.doi.org/10.1007/s10882-016-9497-x. X-1
5585 Lepeta K, Lourenco MV, Schweitzer BC, . Synaptopathies: synaptic dysfunction in neurological disorders. J Neurochem. 2016 Jun 22 doi: 10.1111/jnc.13713. X-1
5586 Leppa VM, Kravitz SN, Martin CL, . Rare Inherited and De Novo CNVs Reveal Complex Contributions to ASD Risk in Multiplex Families. Am J Hum Genet. 2016 Aug 25 doi: 10.1016/j.ajhg.2016.06.036. X-1
5587 Lepper TL, Devine B, Petursdottir AI. Application of a lag contingency to reduce perseveration on circumscribed interests. Dev Neurorehabil. 2016 Apr 8:1–4. doi: 10.3109/17518423.2016.1152612. X-1, X-3
5588 Lera-Miguel S, Rosa M, Puig O, . Assessing advanced theory of mind in children and adolescents with high-functioning autism: The Spanish version of the Stories of Everyday Life. Journal of Autism and Developmental Disorders. 2016;46(1):294–304. doi: http://dx.doi.org/10.1007/s10803-015-2585-4. X-126347232
5589 Lesch KP. Maturing insights into the genetic architecture of neurodevelopmental disorders - from common and rare variant interplay to precision psychiatry. J Child Psychol Psychiatry. 2016 Jun;57(6):659–61. doi: 10.1111/jcpp.12574. X-127192951
5590 Leslie NR, Longy M. Inherited PTEN mutations and the prediction of phenotype. Semin Cell Dev Biol. 2016 Apr;52:30–8. doi: 10.1016/j.semcdb.2016.01.030. X-126827793
5591 Leung C, Chan S, Lam T, . The effect of parent education program for preschool children with developmental disabilities: A randomized controlled trial. Research in Developmental Disabilities. 2016;56:18–28. doi: http://dx.doi.org/10.1016/j.ridd.2016.05.015. X-127258925
5592 Leung C, Jia Z. Mouse Genetic Models of Human Brain Disorders. Front Genet. 2016;7:40. doi: 10.3389/fgene.2016.00040. X-127047540
5593 Levato LE, Aponte CA, Wilkins J, . Use of urine alarms in toilet training children with intellectual and developmental disabilities: A review. Res Dev Disabil. 2016 Jun–Jul;53–54:232–41. doi: 10.1016/j.ridd.2016.02.007. X-1
5594 Leventakou V, Micali N, Georgiou V, . Is there an association between eating behaviour and attention-deficit/hyperactivity disorder symptoms in preschool children? Journal of Child Psychology and Psychiatry. 2016;57(6):676–84. doi: http://dx.doi.org/10.1111/jcpp.12504. X-126706046
5595 Levin K. Aesthetics of hyperactivity: A study of the role of expressive movement in ADHD and capoeira. American Journal of Dance Therapy. 2016;38(1):41–62. doi: http://dx.doi.org/10.1007/s10465-016-9211-7. X-1
5596 Levine SZ, Kodesh A, Goldberg Y, . Initial severity and efficacy of risperidone in autism: Results from the RUPP trial. Eur Psychiatry. 2016 Feb;32:16–20. doi: 10.1016/j.eurpsy.2015.11.004.26802979
5597 Leviton A, Allred EN, Kuban KCK, . Brain disorders associated with corticotropin-releasing hormone expression in the placenta among children born before the 28th week of gestation. Acta Paediatrica. 2016;105(1):e7–e11. doi: http://dx.doi.org/10.1111/apa.13174. X-126331704
5598 Levy SE, Frasso R, Colantonio S, . Shared Decision Making and Treatment Decisions for Young Children With Autism Spectrum Disorder. Acad Pediatr. 2016 Apr 27 doi: 10.1016/j.acap.2016.04.007. X-1
5599 Lewis LF. Realizing a diagnosis of autism spectrum disorder as an adult. Int J Ment Health Nurs. 2016 Mar 4 doi: 10.1111/inm.12200. X-1
5600 Li B, Tadross MR, Tsien RW. Sequential ionic and conformational signaling by calcium channels drives neuronal gene expression. Science. 2016 Feb 19;351(6275):863–7. doi: 10.1126/science.aad3647. X-126912895
5601 Li H, Zhao P, Xu Q, . The autism-related gene SNRPN regulates cortical and spine development via controlling nuclear receptor Nr4a1. Sci Rep. 2016;6:29878. doi: 10.1038/srep29878. X-127430727
5602 Li J, You Y, Yue W, . Chromatin remodeling gene EZH2 involved in the genetic etiology of autism in Chinese Han population. Neurosci Lett. 2016 Jan 1;610:182–6. doi: 10.1016/j.neulet.2015.10.074. X-126552012
5603 Li M, Amuta A, Xu L, . Autism genetic testing information needs among parents of affected children: A qualitative study. Patient Education and Counseling. 2016;99(6):1011–6. doi: http://dx.doi.org/10.1016/j.pec.2015.12.023. X-126847420
5604 Li M, Liu Y. Topoisomerase I in Human Disease Pathogenesis and Treatments. Genomics Proteomics Bioinformatics. 2016 May 12 doi: 10.1016/j.gpb.2016.02.004. X-1
5605 Li M, Zhang ND, Wang Y, . Coordinate regulatory osteogenesis effects of icariin, timosaponin B II and ferulic acid from traditional Chinese medicine formulas on UMR-106 osteoblastic cells and osteoblasts in neonatal rat calvaria cultures. J Ethnopharmacol. 2016 Jun 5;185:120–31. doi: 10.1016/j.jep.2016.03.023. X-126983755
5606 Li M, Zhao H, Ananiev GE, . Establishment of Reporter Lines for Detecting Fragile X Mental Retardation (FMR1) Gene Reactivation in Human Neural Cells. Stem Cells. 2016 Jul 16 doi: 10.1002/stem.2463. X-1
5607 Li P, Zhang C, Yi L. Brief report: Sensitivity of children with autism spectrum disorders to face appearance in selective trust. Journal of Autism and Developmental Disorders. 2016;46(7):2520–5. doi: http://dx.doi.org/10.1007/s10803-016-2761-1. X-126936158
5608 Li Q, Chen CF, Wang DY, . Changes in growth factor levels in the cerebrospinal fluid of autism patients after transplantation of human umbilical cord blood mononuclear cells and umbilical cord-derived mesenchymal stem cells. Genet Mol Res. 2016;15(2)doi: 10.4238/gmr.15027526. X-1
5609 Li Q, Zhou JM. The microbiota-gut-brain axis and its potential therapeutic role in autism spectrum disorder. Neuroscience. 2016 Jun 2;324:131–9. doi: 10.1016/j.neuroscience.2016.03.013. X-126964681
5610 Li YC, Yang SC, Hsu CT, . Capsulated Metallic Debris Tumor Mass Mimicking Adjacent Segment Disease: A Case Report. Clin Spine Surg. 2016 May 11 doi: 10.1097/BSD.0b013e318292e685. X-1
5611 Liao TC, Lien YT, Wang S, . Comorbidity of Atopic Disorders with Autism Spectrum Disorder and Attention Deficit/Hyperactivity Disorder. J Pediatr. 2016 Apr;171:248–55. doi: 10.1016/j.jpeds.2015.12.063. X-126846570
5612 Libero LE, Nordahl CW, Li DD, . Persistence of megalencephaly in a subgroup of young boys with autism spectrum disorder. Autism Res. 2016 Jun 8 doi: 10.1002/aur.1643. X-1
5613 Lim BO, O’Sullivan D, Choi BG, . Comparative gait analysis between children with autism and age-matched controls: analysis with temporal-spatial and foot pressure variables. J Phys Ther Sci. 2016 Jan;28(1):286–92. doi: 10.1589/jpts.28.286. X-126957776
5614 Lim SS. Through the tablet glass: Transcendent parenting in an era of mobile media and cloud computing. Journal of Children and Media. 2016;10(1):21–9. doi: http://dx.doi.org/10.1080/17482798.2015.1121896. X-1
5615 Limberg K, Gruber K, Noterdaeme M. The German version of the Child Behavior Checklist 1.5–5 to identify children with a risk of autism spectrum disorder. Autism. 2016 May 22 doi: 10.1177/1362361316645932. X-1
5616 Lin IF, Agus TR, Suied C, . Fast response to human voices in autism. Sci Rep. 2016;6:26336. doi: 10.1038/srep26336. X-127193919
5617 Lindsay G, Ricketts J, Peacey LV, . Meeting the educational and social needs of children with language impairment or autism spectrum disorder: the parents’ perspectives. Int J Lang Commun Disord. 2016 Mar 8 doi: 10.1111/1460-6984.12226. X-1
5618 Lindsay S. Systematic review of factors affecting driving and motor vehicle transportation among people with autism spectrum disorder. Disabil Rehabil. 2016 Apr 4:1–10. doi: 10.3109/09638288.2016.1161849. X-1, X-2
5619 Lindstrom R, Lepisto-Paisley T, Vanhala R, . Impaired neural discrimination of emotional speech prosody in children with autism spectrum disorder and language impairment. Neurosci Lett. 2016 Jun 9;628:47–51. doi: 10.1016/j.neulet.2016.06.016. X-127291458
5620 Lingren T, Chen P, Bochenek J, . Electronic Health Record Based Algorithm to Identify Patients with Autism Spectrum Disorder. PLoS One. 2016;11(7):e0159621. doi: 10.1371/journal.pone.0159621. X-127472449
5621 Linkovski O, Katzin N, Salti M. Mirror Neurons and Mirror-Touch Synesthesia. Neuroscientist. 2016 May 30 doi: 10.1177/1073858416652079. X-1
5622 Linsell L, Malouf R, Johnson S, . Prognostic factors for behavioral problems and psychiatric disorders in children born very preterm or very low birth weight: A systematic review. Journal of Developmental and Behavioral Pediatrics. 2016;37(1):88–102. X-126703327
5623 Lipstein EA, Lindly OJ, Anixt JS, . Shared Decision Making in the Care of Children with Developmental and Behavioral Disorders. Matern Child Health J. 2016 Mar;20(3):665–73. doi: 10.1007/s10995-015-1866-z. X-126518006
5624 Little EE, Carver LJ, Legare CH. Cultural variation in triadic infant–caregiver object exploration. Child Development. 2016;87(4):1130–45. doi: http://dx.doi.org/10.1111/cdev.12513. X-127018870
5625 Liu CX, Peng XL, Hu CC, . Developmental profiling of ASD-related shank3 transcripts and their differential regulation by valproic acid in zebrafish. Dev Genes Evol. 2016 Aug 26 doi: 10.1007/s00427-016-0561-4. X-1
5626 Liu J, Morey RA, Wilson JK, . Practices and outcomes of self-treatment with helminths based on physicians’ observations. J Helminthol. 2016 May 31:1–11. doi: 10.1017/s0022149x16000316. X-1
5627 Liu W, Li M, Yi L. Identifying children with autism spectrum disorder based on their face processing abnormality: A machine learning framework. Autism Res. 2016 Apr 1 doi: 10.1002/aur.1615. X-1
5628 Liu X, Campanac E, Cheung HH, . Idiopathic Autism: Cellular and Molecular Phenotypes in Pluripotent Stem Cell-Derived Neurons. Mol Neurobiol. 2016 Jun 29 doi: 10.1007/s12035-016-9961-8. X-1
5629 Liu Y, Ao NI, Zhao H. Gallbladder agenesis and atrial septal defect: A case report. Exp Ther Med. 2016 May;11(5):1795–8. doi: 10.3892/etm.2016.3115. X-127168805
5630 Liu Z, Li X, Zhang JT, . Autism-like behaviours and germline transmission in transgenic monkeys overexpressing MeCP2. Nature. 2016 Feb 4;530(7588):98–102. doi: 10.1038/nature16533. X-126808898
5631 Lo FS, Erzurumlu RS, Powell EM. Insulin-Independent GABAA Receptor-Mediated Response in the Barrel Cortex of Mice with Impaired Met Activity. J Neurosci. 2016 Mar 30;36(13):3691–7. doi: 10.1523/jneurosci.0006-16.2016. X-127030755
5632 Lockwood PL. The anatomy of empathy: Vicarious experience and disorders of social cognition. Behav Brain Res. 2016 Sep 15;311:255–66. doi: 10.1016/j.bbr.2016.05.048. X-127235714
5633 Loebel A, Brams M, Goldman RS, . Lurasidone for the treatment of irritability associated with autistic disorder. Journal of Autism and Developmental Disorders. 2016;46(4):1153–63. doi: http://dx.doi.org/10.1007/s10803-015-2628-x. X-1, X-426659550
5634 Longo N, Frigeni M, Pasquali M. Carnitine transport and fatty acid oxidation. Biochim Biophys Acta. 2016 Jan 29 doi: 10.1016/j.bbamcr.2016.01.023. X-1
5635 Lopata C, Lipinski AM, Thomeer ML, . Open-trial pilot study of a comprehensive outpatient psychosocial treatment for children with high-functioning autism spectrum disorder. Autism. 2016 Apr 7 doi: 10.1177/1362361316630201. X-3
5636 Lopata C, Thomeer ML, Rodgers JD, . RCT of mind reading as a component of a psychosocial treatment for high-functioning children with ASD. Research in Autism Spectrum Disorders. 2016;21:25–36. doi: http://dx.doi.org/10.1016/j.rasd.2015.09.003. X-1
5637 Lopes F, Barbosa M, Ameur A, . Identification of novel genetic causes of Rett syndrome-like phenotypes. J Med Genet. 2016 Mar;53(3):190–9. doi: 10.1136/jmedgenet-2015-103568. X-126740508
5638 Lopez-Cacho JM, Gallardo S, Posada M, . Characterization of immune cell phenotypes in adults with autism spectrum disorders. J Investig Med. 2016 Jun 13 doi: 10.1136/jim-2016-000070. X-1
5639 Lopez-Mourelo O, Mur E, Madrigal I, . Social anxiety and autism spectrum traits among adult FMR1 premutation carriers. Clin Genet. 2016 Apr 22 doi: 10.1111/cge.12791. X-1
5640 Lord C, Veenstra-VanderWeele J. Following the Trail From Genotype to Phenotypes. JAMA Psychiatry. 2016 Jan;73(1):7–8. doi: 10.1001/jamapsychiatry.2015.2344. X-126630619
5641 Lorenz T, Frischling C, Cuadros R, . Autism and Overcoming Job Barriers: Comparing Job-Related Barriers and Possible Solutions in and outside of Autism-Specific Employment. PLoS One. 2016;11(1):e0147040. doi: 10.1371/journal.pone.0147040. X-126766183
5642 Lorenzo G, Lledó A, Pomares J, . Design and application of an immersive virtual reality system to enhance emotional skills for children with autism spectrum disorders. Computers & Education. 2016;98:192–205. doi: http://dx.doi.org/10.1016/j.compedu.2016.03.018. X-1
5643 Loring WA, Johnston R, Gray L, . A brief behavioral intervention for insomnia in adolescents with autism spectrum disorders. Clinical Practice in Pediatric Psychology. 2016;4(2):112–24. doi: http://dx.doi.org/10.1037/cpp0000141. X-1, X-3
5644 Loth E, Spooren W, Ham LM, . Identification and validation of biomarkers for autism spectrum disorders. Nat Rev Drug Discov. 2016 Jan;15(1):70–3. doi: 10.1038/nrd.2015.7. X-126718285
5645 Lough E, Fisher MH. Parent and Self-Report Ratings on the Perceived Levels of Social Vulnerability of Adults with Williams Syndrome. J Autism Dev Disord. 2016 Aug 9 doi: 10.1007/s10803-016-2885-3. X-1
5646 Loukisas TD, Papoudi D. Mothers’ experiences of children in the autistic spectrum in Greece: Narratives of development, education and disability across their blogs. International Journal of Disability, Development and Education. 2016;63(1):64–78. doi: http://dx.doi.org/10.1080/1034912X.2015.1111304. X-1
5647 Louros SR, Osterweil EK. Perturbed proteostasis in autism spectrum disorders. J Neurochem. 2016 Jul 1 doi: 10.1111/jnc.13723. X-1
5648 Loveall SJ, Channell MM, Phillips BA, . Receptive vocabulary analysis in Down syndrome. Research in Developmental Disabilities. 2016;55:161–72. doi: http://dx.doi.org/10.1016/j.ridd.2016.03.018. X-127084992
5649 Lovelace JW, Wen TH, Reinhard S, . Matrix metalloproteinase-9 deletion rescues auditory evoked potential habituation deficit in a mouse model of Fragile X Syndrome. Neurobiol Dis. 2016 May;89:126–35. doi: 10.1016/j.nbd.2016.02.002. X-126850918
5650 Lovell B, Wetherell MA. Behaviour problems of children with ASD and perceived stress in their caregivers: The moderating role of trait emotional intelligence? Research in Autism Spectrum Disorders. 2016;28:1–6. doi: http://dx.doi.org/10.1016/j.rasd.2016.05.002. X-1
5651 Loviglio MN, Leleu M, Mannik K, . Chromosomal contacts connect loci associated with autism, BMI and head circumference phenotypes. Mol Psychiatry. 2016 May 31 doi: 10.1038/mp.2016.84. X-1
5652 Lozano R, Saito N, Reed D, . Aging in Fragile X Premutation Carriers. Cerebellum. 2016 Jun 22 doi: 10.1007/s12311-016-0805-x. X-1
5653 Lu C, Qi Z, Harris A, . Shared neuroanatomical substrates of impaired phonological working memory across reading disability and autism. Biol Psychiatry Cogn Neurosci Neuroimaging. 2016 Mar 1;1(2):169–77. doi: 10.1016/j.bpsc.2015.11.001. X-126949750
5654 Luchsinger K, Lau H, Hedlund JL, . Parental-reported pain insensitivity in Dup15q. Epilepsy & Behavior. 2016;55:124–7. doi: http://dx.doi.org/10.1016/j.yebeh.2015.10.007. X-126773682
5655 Ludlow AK, Wilkins AJ. Atypical Sensory behaviours in children with Tourette’s Syndrome and in children with Autism Spectrum Disorders. Res Dev Disabil. 2016 Sep;56:108–16. doi: 10.1016/j.ridd.2016.05.019. X-127286465
5656 Lushchekina EA, Khaerdinova OY, Novototskii-Vlasov VY, . Synchronization of EEG rhythms in baseline conditions and during counting in children with autism spectrum disorders. Neuroscience and Behavioral Physiology. 2016;46(4):382–9. doi: http://dx.doi.org/10.1007/s11055-016-0246-5. X-1
5657 Luxford S, Hadwin JA, Kovshoff H. Evaluating the Effectiveness of a School-Based Cognitive Behavioural Therapy Intervention for Anxiety in Adolescents Diagnosed with Autism Spectrum Disorder. J Autism Dev Disord. 2016 Jul 20 doi: 10.1007/s10803-016-2857-7. X-1
5658 Lyons GL, Huber HB, Carter EW, . Assessing the Social Skills and Problem Behaviors of Adolescents With Severe Disabilities Enrolled in General Education Classes. Am J Intellect Dev Disabil. 2016 Jul;121(4):327–45. doi: 10.1352/1944-7558-121.4.327. X-127351700
5659 Ma NS, Thompson C, Weston S. Brief report: Scurvy as a manifestation of food selectivity in children with autism. Journal of Autism and Developmental Disorders. 2016;46(4):1464–70. doi: http://dx.doi.org/10.1007/s10803-015-2660-x. X-126590972
5660 Mache MA, Todd TA. Gross motor skills are related to postural stability and age in children with autism spectrum disorder. Research in Autism Spectrum Disorders. 2016;23:179–87. doi: http://dx.doi.org/10.1016/j.rasd.2016.01.001. X-1
5661 Macizo P, Soriano MF, Paredes N. Phonological and Visuospatial Working Memory in Autism Spectrum Disorders. J Autism Dev Disord. 2016 Jun 17 doi: 10.1007/s10803-016-2835-0. X-1
5662 Macoun SJ, Kerns KA. Evidence of motor-control difficulties in children with attention deficit hyperactivity disorder, explored through a hierarchical motor-systems perspective. Journal of Clinical and Experimental Neuropsychology. 2016;38(2):183–96. doi: http://dx.doi.org/10.1080/13803395.2015.1094028. X-126595141
5663 Maddox BB, Miyazaki Y, White SW. Long-Term Effects of CBT on Social Impairment in Adolescents with ASD. J Autism Dev Disord. 2016 Apr 4 doi: 10.1007/s10803-016-2779-4. X-1, X-4
5664 Maddox BB, Trubanova A, White SW. Untended wounds: Non-suicidal self-injury in adults with autism spectrum disorder. Autism. 2016 May 12 doi: 10.1177/1362361316644731. X-1
5665 Magana S, Parish SL, Son E. Functional severity and Latino ethnicity in specialty services for children with autism spectrum disorder. J Intellect Disabil Res. 2016 May;60(5):424–34. doi: 10.1111/jir.12293. X-127120986
5666 Magliaro C, Cocito C, Bagatella S, . The number of Purkinje neurons and their topology in the cerebellar vermis of normal and reln haplodeficient mouse. Ann Anat. 2016 Mar 17 doi: 10.1016/j.aanat.2016.02.009. X-1
5667 Magnúsdóttir K, Saemundsen E, Einarsson BL, . The impact of attention deficit/hyperactivity disorder on adaptive functioning in children diagnosed late with autism spectrum disorder—A comparative analysis. Research in Autism Spectrum Disorders. 2016;23:28–35. doi: http://dx.doi.org/10.1016/j.rasd.2015.11.012. X-1
5668 Mahaj M, Sharkia R, Shorbaji N, . Clinical Profile of Attention Deficit Hyperactivity Disorder: Impact of Ethnic and Social Diversities in Israel. Isr Med Assoc J. 2016 Jun;18(6):322–5. X-127468523
5669 Mahoney G, Solomon R. Mechanism of developmental change in the PLAY Project Home Consultation Intervention Program: Evidence from a randomized control trial. Journal of Autism and Developmental Disorders. 2016;46(5):1860–71. doi: http://dx.doi.org/10.1007/s10803-016-2720-x. X-126830414
5670 Maïano C, Normand CL, Salvas MC, . Prevalence of school bullying among youth with autism spectrum disorders: A systematic review and meta-analysis. Autism Research. 2016;9(6):601–15. doi: http://dx.doi.org/10.1002/aur.1568. X-126451871
5671 Mailend ML, Plante E, Anderson MA, . Reliability of the Test of Integrated Language and Literacy Skills (TILLS). International Journal of Language & Communication Disorders. 2016;51(4):447–59. doi: http://dx.doi.org/10.1111/1460-6984.12222. X-127018642
5672 Maillard AM, Hippolyte L, Rodriguez-Herreros B, . 16p11.2 Locus modulates response to satiety before the onset of obesity. Int J Obes (Lond). 2016 May;40(5):870–6. doi: 10.1038/ijo.2015.247. X-126620891
5673 Maisel ME, Stephenson KG, South M, . Modeling the cognitive mechanisms linking autism symptoms and anxiety in adults. J Abnorm Psychol. 2016 Jul;125(5):692–703. doi: 10.1037/abn0000168. X-127196436
5674 Majdalany L, Wilder DA, Smeltz L, . The effect of brief delays to reinforcement on the acquisition of tacts in children with autism. J Appl Behav Anal. 2016 Jun;49(2):411–5. doi: 10.1002/jaba.282. X-1, X-426792114
5675 Majoko T. Inclusion of children with autism spectrum disorders: Listening and hearing to voices from the grassroots. Journal of Autism and Developmental Disorders. 2016;46(4):1429–40. doi: http://dx.doi.org/10.1007/s10803-015-2685-1. X-126715013
5676 Malinverni L, Mora-Guiard J, Pares N. Towards methods for evaluating and communicating participatory design: A multimodal approach. International Journal of Human-Computer Studies. 2016;94:53–63. doi: http://dx.doi.org/10.1016/j.ijhcs.2016.03.004. X-1
5677 Malow BA, Connolly HV, Weiss SK, . The Pediatric Sleep Clinical Global Impressions Scale—A new tool to measure pediatric insomnia in autism spectrum disorders. Journal of Developmental and Behavioral Pediatrics. 2016;37(5):370–6. doi: http://dx.doi.org/10.1097/DBP.0000000000000307. X-127244298
5678 Malow BA, MacDonald LL, Fawkes DB, . Teaching children with autism spectrum disorder how to sleep better: A pilot educational program for parents. Clinical Practice in Pediatric Psychology. 2016;4(2):125–36. doi: http://dx.doi.org/10.1037/cpp0000138. X-3
5679 Maltete D. Adult-onset stereotypical motor behaviors. Rev Neurol (Paris). 2016 Aug 3 doi: 10.1016/j.neurol.2016.07.002. X-1
5680 Mammas IN, Greenough A, Theodoridou M, . Current views and advances on Paediatric Virology: An update for paediatric trainees. Exp Ther Med. 2016 Jan;11(1):6–14. doi: 10.3892/etm.2015.2890. X-126889211
5681 Mancil GR, Haydon T, Boman M. Differentiated effects of sensory activities as abolishing operations via non-contingent reinforcement on academic and aberrant behavior. Education and Training in Autism and Developmental Disabilities. 2016;51(1):93–104. X-3, X-4
5682 Mandell DS, Barry CL, Marcus SC, . Effects of Autism Spectrum Disorder Insurance Mandates on the Treated Prevalence of Autism Spectrum Disorder. JAMA Pediatr. 2016 Jul 11 doi: 10.1001/jamapediatrics.2016.1049. X-1
5683 Manduca A, Servadio M, Damsteegt R, . Dopaminergic Neurotransmission in the Nucleus Accumbens Modulates Social Play Behavior in Rats. Neuropsychopharmacology. 2016 Feb 10 doi: 10.1038/npp.2016.22. X-1
5684 Marchese M, Valvo G, Moro F, . Targeted gene resequencing (astrochip) to explore the tripartite synapse in autism–epilepsy phenotype with macrocephaly. NeuroMolecular Medicine. 2016;18(1):69–80. doi: http://dx.doi.org/10.1007/s12017-015-8378-2. X-126537360
5685 Marchetto MC, Belinson H, Tian Y, . Altered proliferation and networks in neural cells derived from idiopathic autistic individuals. Mol Psychiatry. 2016 Jul 5 doi: 10.1038/mp.2016.95. X-1
5686 Mariano M, Pino MC, Peretti S, . Understanding criminal behavior: Empathic impairment in criminal offenders. Soc Neurosci. 2016 May 9:1–7. doi: 10.1080/17470919.2016.1179670. X-1
5687 Mari-Bauset S, Llopis-Gonzalez A, Zazpe I, . Comparison of nutritional status between children with autism spectrum disorder and typically developing children in the Mediterranean Region (Valencia, Spain). Autism. 2016 Apr 30 doi: 10.1177/1362361316636976. X-1
5688 Marko D, Boege F. A possible link between nutritional uptake of ubiquitous topoisomerase inhibitors and autism? Int J Dev Neurosci. 2016 Jun 11;53:8–9. doi: 10.1016/j.ijdevneu.2016.06.003. X-127296517
5689 Marshall D, Wright B, Allgar V, . Social Stories in mainstream schools for children with autism spectrum disorder: a feasibility randomised controlled trial. BMJ Open. 2016;6(8):e011748. doi: 10.1136/bmjopen-2016-011748. X-1
5690 Martin BS, Martinez-Botella G, Loya CM, . Rescue of deficient amygdala tonic gamma-aminobutyric acidergic currents in the Fmr(−/y) mouse model of fragile X syndrome by a novel gamma-aminobutyric acid type A receptor-positive allosteric modulator. J Neurosci Res. 2016 Jun;94(6):568–78. doi: 10.1002/jnr.23632. X-126308557
5691 Martin S, Lazzarini M, Dullin C, . SK3 Channel Overexpression in Mice Causes Hippocampal Shrinkage Associated with Cognitive Impairments. Mol Neurobiol. 2016 Jan 23 doi: 10.1007/s12035-015-9680-6. X-1
5692 Martinez CK, Betz AM, Liddon CJ, . A progression to transfer RIRD to the natural environment. Behavioral Interventions. 2016;31(2):144–62. doi: http://dx.doi.org/10.1002/bin.1444. X-1
5693 Martin-Trias P, Bragulat V, Pena-Gomez C, . Translational challenge models in support of efficacy studies: Neurobehavioral and cognitive changes induced by Transcranial Magnetic Stimulation in healthy volunteers. CNS Neurol Disord Drug Targets. 2016 May 18. X-1
5694 Mashayekhi F, Mizban N, Bidabadi E, . The association of SHANK3 gene polymorphism and autism. Minerva Pediatr. 2016 Jun 8. X-1
5695 Mason LL, Davis D, Andrews A. Mentalistic explanations for autistic behavior: A behavioral phenomenological analysis. Behavior and Philosophy. 2016;43:62–84. X-1
5696 Masse JJ, McNeil CB, Wagner S, . Examining the efficacy of parent–child interaction therapy with children on the autism spectrum. Journal of Child and Family Studies. 2016;25(8):2508–25. doi: http://dx.doi.org/10.1007/s10826-016-0424-7. X-3, X-4
5697 Matson JL, Cervantes PE, Peters WJ. Autism spectrum disorders: management over the lifespan. Expert Rev Neurother. 2016 Jun 30:1–10. doi: 10.1080/14737175.2016.1203255. X-1
5698 Matsushima K, Matsubayashi J, Toichi M, . Unusual sensory features are related to resting-state cardiac vagus nerve activity in autism spectrum disorders. Research in Autism Spectrum Disorders. 2016;25:37–46. doi: http://dx.doi.org/10.1016/j.rasd.2015.12.006. X-1
5699 Mattila I, Patila T, Rautiainen P, . The effect of continuous wound infusion of ropivacaine on postoperative pain after median sternotomy and mediastinal drain in children. Paediatr Anaesth. 2016 Jul;26(7):727–33. doi: 10.1111/pan.12919. X-127184591
5700 Maule J, Stanworth K, Pellicano E, . Color Afterimages in Autistic Adults. J Autism Dev Disord. 2016 Apr 28 doi: 10.1007/s10803-016-2786-5. X-1
5701 May T, Cornish K, Rinehart NJ. Exploring factors related to the anger superiority effect in children with Autism Spectrum Disorder. Brain and Cognition. 2016;106:65–71. doi: http://dx.doi.org/10.1016/j.bandc.2016.05.004. X-1, X-327258410
5702 May T, McGinley J, Murphy A, . A multidisciplinary perspective on motor impairment as an early behavioural marker in children with autism spectrum disorder. Australian Psychologist. 2016;51(4):296–303. doi: http://dx.doi.org/10.1111/ap.12225. X-1, X-2
5703 Mayer JL, Hannent I, Heaton PF. Mapping the developmental trajectory and correlates of enhanced pitch perception on speech processing in adults with ASD. Journal of Autism and Developmental Disorders. 2016;46(5):1562–73. doi: http://dx.doi.org/10.1007/s10803-014-2207-6. X-125106823
5704 Maynard DW, McDonald TA, Stickle T. Parents as a team: Mother, father, a child with autism spectrum disorder, and a spinning toy. Journal of Autism and Developmental Disorders. 2016;46(2):406–23. doi: http://dx.doi.org/10.1007/s10803-015-2568-5. X-1, X-3, X-426494576
5705 Mazahery H, Conlon C, Beck KL, . Vitamin D and omega-3 fatty acid supplements in children with autism spectrum disorder: a study protocol for a factorial randomised, double-blind, placebo-controlled trial. Trials. 2016;17(1):295. doi: 10.1186/s13063-016-1428-8. X-127334138
5706 Mazurek MO, Brown R, Curran A, . ECHO Autism: A New Model for Training Primary Care Providers in Best-Practice Care for Children With Autism. Clin Pediatr (Phila). 2016 May 11 doi: 10.1177/0009922816648288. X-1
5707 Mazurek MO, Engelhardt CR, Hilgard J, . Bedtime Electronic Media Use and Sleep in Children with Autism Spectrum Disorder. J Dev Behav Pediatr. 2016 Jun 28 doi: 10.1097/dbp.0000000000000314. X-1, X-3
5708 Mazurek MO, Sohl K. Sleep and behavioral problems in children with autism spectrum disorder. Journal of Autism and Developmental Disorders. 2016;46(6):1906–15. doi: http://dx.doi.org/10.1007/s10803-016-2723-7. X-126823076
5709 McCarthy A, Asghar S, Wilens T, . Using a brief parent-report measure to track outcomes for children and teens with ADHD. Child Psychiatry and Human Development. 2016;47(3):407–16. doi: http://dx.doi.org/10.1007/s10578-015-0575-6. X-126271346
5710 McClendon J, Jr, Graham RB, Sugrue PA, . Cranial Center of Mass Compared to C7 Plumb Line Alignment in Adult Spinal Deformity. World Neurosurg. 2016 Mar 30 doi: 10.1016/j.wneu.2016.03.078. X-1
5711 McConkey R, Kelly C, Craig S, . A decade of change in mainstream education for children with intellectual disabilities in the Republic of Ireland. European Journal of Special Needs Education. 2016;31(1):96–110. doi: http://dx.doi.org/10.1080/08856257.2015.1087151. X-1
5712 McCormick C, Hepburn S, Young GS, . Sensory symptoms in children with autism spectrum disorder, other developmental disorders and typical development: A longitudinal study. Autism. 2016 Jul;20(5):572–9. doi: 10.1177/1362361315599755. X-126395236
5713 McCoy SM, Jakicic JM, Gibbs BB. Comparison of obesity, physical activity, and sedentary behaviors between adolescents with autism spectrum disorders and without. Journal of Autism and Developmental Disorders. 2016;46(7):2317–26. doi: http://dx.doi.org/10.1007/s10803-016-2762-0. X-126936162
5714 McDaniels J. Family Advocates for Parents With Children With an Autism Spectrum Disorder. A Letter to the Editor on the Article “Parent Perceptions of Care Received by Children With an Autism Spectrum Disorder”. J Pediatr Nurs.. 2016 May 9 doi: 10.1016/j.pedn.2016.04.005. X-1
5715 McDonald NM, Baker JK, Messinger DS. Oxytocin and parent–child interaction in the development of empathy among children at risk for autism. Developmental Psychology. 2016;52(5):735–45. doi: http://dx.doi.org/10.1037/dev0000104. X-126998571
5716 McDougall J, Baldwin P, Evans J, . Quality of life and self-determination: Youth with chronic health conditions make the connection. Applied Research in Quality of Life. 2016;11(2):571–99. doi: http://dx.doi.org/10.1007/s11482-014-9382-7. X-127398103
5717 McEwen FS, Stewart CS, Colvert E, . Diagnosing autism spectrum disorder in community settings using the Development and Well-Being Assessment: Validation in a UK population-based twin sample. Journal of Child Psychology and Psychiatry. 2016;57(2):161–70. doi: http://dx.doi.org/10.1111/jcpp.12447. X-126174111
5718 McGrane IR, Loveland JG, Zaluski HJ. Adjunctive Amantadine Treatment for Aggressive Behavior in Children: A Series of Eight Cases. J Child Adolesc Psychopharmacol. 2016 Aug 2 doi: 10.1089/cap.2016.0042. X-1
5719 McGrath LM, Braaten EB, Doty ND, . Extending the ‘cross-disorder’ relevance of executive functions to dimensional neuropsychiatric traits in youth. Journal of Child Psychology and Psychiatry. 2016;57(4):462–71. doi: http://dx.doi.org/10.1111/jcpp.12463. X-126411927
5720 McGrath LM, Oates JM, Dai YG, . Attention Bias to Emotional Faces Varies by IQ and Anxiety in Williams Syndrome. J Autism Dev Disord. 2016 Jun;46(6):2174–85. doi: 10.1007/s10803-016-2748-y. X-126886469
5721 McHale P, Keenan A, Ghebrehewet S. Reasons for measles cases not being vaccinated with MMR: investigation into parents’ and carers’ views following a large measles outbreak. Epidemiol Infect. 2016 Mar;144(4):870–5. doi: 10.1017/s0950268815001909. X-126265115
5722 McKenna C. Review of Autism spectrum disorder in children and adolescents: Evidence-based assessment and intervention in schools. Child and Adolescent Mental Health. 2016;21(2):136. doi: http://dx.doi.org/10.1111/camh.12135. X-1, X-2
5723 McKenzie K, Forsyth K, O’Hare A, . The relationship between waiting times and ‘adherence’ to the Scottish Intercollegiate Guidelines Network 98 guideline in autism spectrum disorder diagnostic services in Scotland. Autism. 2016;20(4):395–401. doi: http://dx.doi.org/10.1177/1362361315586136. X-126033259
5724 McKenzie K, Ouellette-Kuntz H, Blinkhorn A, . Out of School and Into Distress: Families of Young Adults with Intellectual and Developmental Disabilities in Transition. J Appl Res Intellect Disabil. 2016 Jun 9 doi: 10.1111/jar.12264. X-1
5725 McKinnon A, Brewer N, Meiser-Stedman R, . Trauma memory characteristics and the development of acute stress disorder and post-traumatic stress disorder in youth. J Behav Ther Exp Psychiatry. 2016 Jul 22;54:112–9. doi: 10.1016/j.jbtep.2016.07.009. X-127467024
5726 McKnight LM, O’Malley-Keighran MP, Carroll C. ‘Just wait then and see what he does’: a speech act analysis of healthcare professionals’ interaction coaching with parents of children with autism spectrum disorders. Int J Lang Commun Disord. 2016 Jun 9 doi: 10.1111/1460-6984.12246. X-1
5727 McLay L, Church J, Sutherland D. Variables affecting the emergence of untaught equivalence relations in children with and without autism. Developmental Neurorehabilitation. 2016;19(2):75–87. X-1, X-324784794
5728 McMahon CM, Henderson HA, Newell L, . Metacognitive awareness of facial affect in higher-functioning children and adolescents with autism spectrum disorder. Journal of Autism and Developmental Disorders. 2016;46(3):882–98. doi: http://dx.doi.org/10.1007/s10803-015-2630-3. X-126496991
5729 McManus BM, Robinson CC, Rosenberg SA. Identifying infants and toddlers at high risk for persistent delays. Maternal and Child Health Journal. 2016;20(3):639–45. doi: http://dx.doi.org/10.1007/s10995-015-1863-2. X-126518005
5730 Meador KJ, Loring DW. Developmental effects of antiepileptic drugs and the need for improved regulations. Neurology. 2016 Jan 19;86(3):297–306. doi: 10.1212/wnl.0000000000002119. X-126519545
5731 Medhasi S, Pasomsub E, Vanwong N, . Clinically relevant genetic variants of drug-metabolizing enzyme and transporter genes detected in Thai children and adolescents with autism spectrum disorder. Neuropsychiatric Disease and Treatment. 2016;12. X-1
5732 Mei Y, Monteiro P, Zhou Y, . Adult restoration of Shank3 expression rescues selective autistic-like phenotypes. Nature. 2016 Feb 25;530(7591):481–4. doi: 10.1038/nature16971. X-126886798
5733 Meisel HJ, Jurak L, Antinheimo J, . Four-year results of a prospective single-arm study on 200 semi-constrained total cervical disc prostheses: clinical and radiographic outcome. J Neurosurg Spine. 2016 Jun 3:1–10. doi: 10.3171/2016.3.spine15810. X-1
5734 Menassa DA, Sloan C, Chance SA. Primary olfactory cortex in autism and epilepsy: Increased glial cells in autism. Brain Pathol. 2016 Jul 13 doi: 10.1111/bpa.12415. X-1
5735 Mendelson JL, Gates JA, Lerner MD. Friendship in school-age boys with autism spectrum disorders: A meta-analytic summary and developmental, process-based model. Psychological Bulletin. 2016;142(6):601–22. doi: http://dx.doi.org/10.1037/bul0000041. X-1, X-226752425
5736 Meng WD, Sun SJ, Yang J, . Elevated Serum Brain-Derived Neurotrophic Factor (BDNF) but not BDNF Gene Val66Met Polymorphism Is Associated with Autism Spectrum Disorders. Mol Neurobiol. 2016 Jan 28 doi: 10.1007/s12035-016-9721-9. X-1
5737 Meng X, Wang W, Lu H, . Manipulations of MeCP2 in glutamatergic neurons highlight their contributions to Rett and other neurological disorders. Elife. 2016 Jun 21;5 doi: 10.7554/eLife.14199. X-1
5738 Menga EN, Spiegel MA, Vira S, . Variability Over Time of Preoperative Sagittal Alignment Parameters: Radiographic and Clinical Considerations. Spine (Phila Pa 1976). 2016 Apr 23 doi: 10.1097/brs.0000000000001648. X-1
5739 Meppelink R, de Bruin EI, Bögels SM. Meditation or Medication? Mindfulness training versus medication in the treatment of childhood ADHD: A randomized controlled trial. BMC Psychiatry. 2016;16. X-1
5740 Mercado E, 3rd, Church BA. Brief Report: Simulations Suggest Heterogeneous Category Learning and Generalization in Children with Autism is a Result of Idiosyncratic Perceptual Transformations. J Autism Dev Disord. 2016 May 18 doi: 10.1007/s10803-016-2815-4. X-1
5741 Mercati O, Huguet G, Danckaert A, . CNTN6 mutations are risk factors for abnormal auditory sensory perception in autism spectrum disorders. Mol Psychiatry. 2016 May 10 doi: 10.1038/mp.2016.61. X-1
5742 Merner N, Forgeot d’Arc B, Bell SC, . A de novo frameshift mutation in chromodomain helicase DNA-binding domain 8 (CHD8): A case report and literature review. Am J Med Genet A. 2016 May;170(5):1225–35. doi: 10.1002/ajmg.a.37566. X-1
5743 Merner ND, Mercado A, Khanna AR, . Gain-of-function missense variant in SLC12A2, encoding the bumetanide-sensitive NKCC1 cotransporter, identified in human schizophrenia. J Psychiatr Res. 2016 Jun;77:22–6. doi: 10.1016/j.jpsychires.2016.02.016. X-126955005
5744 Merrick AD, Grieve A, Cogan N. Psychological impacts of challenging behaviour and motivational orientation in staff supporting individuals with autistic spectrum conditions. Autism. 2016 Jun 26 doi: 10.1177/1362361316654857. X-1
5745 Mevel K, Fransson P. The functional brain connectome of the child and autism spectrum disorders. Acta Paediatr. 2016 May 26 doi: 10.1111/apa.13484. X-1
5746 Meziane H, Khelfaoui M, Morello N, . Fasudil treatment in adult reverses behavioural changes and brain ventricular enlargement in Oligophrenin-1 mouse model of intellectual disability. Hum Mol Genet. 2016 May 4 doi: 10.1093/hmg/ddw102. X-1
5747 Mhatre D, Bapat D, Udani V. Long-term outcomes in children diagnosed with autism spectrum disorders in India. Journal of Autism and Developmental Disorders. 2016;46(3):760–72. doi: http://dx.doi.org/10.1007/s10803-015-2613-4. X-126428354
5748 Micalizzi L, Ronald A, Saudino KJ. A genetically informed cross-lagged analysis of autistic-like traits and affective problems in early childhood. Journal of Abnormal Child Psychology. 2016;44(5):937–47. doi: http://dx.doi.org/10.1007/s10802-015-0088-6. X-126456961
5749 Michna I, Trestman R. Correctional Management and Treatment of Autism Spectrum Disorder. J Am Acad Psychiatry Law. 2016 Jun;44(2):253–8. X-127236182
5750 Mieses AM, Tavassoli T, Li E, . Brief Report: Sensory Reactivity in Children with Phelan-McDermid Syndrome. J Autism Dev Disord. 2016 Jul;46(7):2508–13. doi: 10.1007/s10803-016-2754-0. X-126914612
5751 Mieses AM, Tavassoli T, Li E, . Brief report: Sensory reactivity in children with Phelan–McDermid syndrome. Journal of Autism and Developmental Disorders. 2016;46(7):2508–13. doi: http://dx.doi.org/10.1007/s10803-016-2754-0. X-126914612
5752 Mihic T, Rainkie D, Wilby KJ, . The Therapeutic Effects of Camel Milk: A Systematic Review of Animal and Human Trials. J Evid Based Complementary Altern Med. 2016 Jul 18 doi: 10.1177/2156587216658846. X-1, X-2
5753 Miller M, Iosif AM, Young GS, . School-age outcomes of infants at risk for autism spectrum disorder. Autism Research. 2016;9(6):632–42. doi: http://dx.doi.org/10.1002/aur.1572. X-126451968
5754 Miller NA, Merryman MB, Eskow KG, . State Design and Use of Medicaid 1915(c) Waivers and Related Benefits to Provide Services to Children and Youth With Autism Spectrum Disorder. Am J Intellect Dev Disabil. 2016 Jul;121(4):295–311. doi: 10.1352/1944-7558-121.4.295. X-127351698
5755 Mills BD, Pearce HL, Khan O, . Prenatal domoic acid exposure disrupts mouse pro-social behavior and functional connectivity MRI. Behav Brain Res. 2016 Jul 15;308:14–23. doi: 10.1016/j.bbr.2016.03.039. X-127050322
5756 Milosavljevic B, Carter Leno V, Simonoff E, . Alexithymia in adolescents with autism spectrum disorder: Its relationship to internalising difficulties, sensory modulation and social cognition. Journal of Autism and Developmental Disorders. 2016;46(4):1354–67. doi: http://dx.doi.org/10.1007/s10803-015-2670-8. X-126659552
5757 Ming X, Patel R, Kang V, . Respiratory and autonomic dysfunction in children with autism spectrum disorders. Brain & Development. 2016;38(2):225–32. doi: http://dx.doi.org/10.1016/j.braindev.2015.07.003. X-126235973
5758 Minshawi NF, Wink LK, Shaffer R, . A randomized, placebo-controlled trial of D-cycloserine for the enhancement of social skills training in autism spectrum disorders. Mol Autism. 2016;7:2. doi: 10.1186/s13229-015-0062-8. X-126770664
5759 Mintz M. Evolution in the Understanding of Autism Spectrum Disorder: Historical Perspective. Indian J Pediatr. 2016 Apr 7 doi: 10.1007/s12098-016-2080-8. X-1, X-2, X-3
5760 Mitra A, Zhu W, Kesisoglou F. Physiologically Based Absorption Modeling for Amorphous Solid Dispersion Formulations. Mol Pharm. 2016 Jul 29 doi: 10.1021/acs.molpharmaceut.6b00424. X-1
5761 Miyajima M, Omiya H, Yamashita K, . The effects of cognitive remediation therapy using the frontal/executive program for autism spectrum disorder. Int J Psychiatry Med. 2016 Apr;51(3):223–35. doi: 10.1177/0091217416651254. X-1, X-427284115
5762 Miyawaki D, Iwakura Y, Seto T, . Psychogenic nonepileptic seizures as a manifestation of psychological distress associated with undiagnosed autism spectrum disorder. Neuropsychiatric Disease and Treatment. 2016;12. X-1
5763 Mizukami T, Kohno T, Hattori M. CUB and Sushi multiple domains 3 regulates dendrite development. Neurosci Res. 2016 Mar 28 doi: 10.1016/j.neures.2016.03.003. X-1
5764 Moavero R, Napolitano A, Cusmai R, . White matter disruption is associated with persistent seizures in tuberous sclerosis complex. Epilepsy & Behavior. 2016;60:63–7. doi: http://dx.doi.org/10.1016/j.yebeh.2016.04.026. X-127179194
5765 Modabbernia A, Mollon J, Boffetta P, . Impaired gas exchange at birth and risk of intellectual disability and autism: A meta-analysis. Journal of Autism and Developmental Disorders. 2016;46(5):1847–59. doi: http://dx.doi.org/10.1007/s10803-016-2717-5. X-126820632
5766 Modabbernia A, Velthorst E, Gennings C, . Early-life metal exposure and schizophrenia: A proof-of-concept study using novel tooth-matrix biomarkers. Eur Psychiatry. 2016 Jun 13;36:1–6. doi: 10.1016/j.eurpsy.2016.03.006. X-127311101
5767 Modi ME, Majchrzak MJ, Fonseca KR, . Peripheral Administration of a Long-Acting Peptide Oxytocin Receptor Agonist Inhibits Fear-Induced Freezing. J Pharmacol Exp Ther. 2016 Aug;358(2):164–72. doi: 10.1124/jpet.116.232702. X-127217590
5768 Mohamed FE, Zaky EA, Youssef A, . Screening of Egyptian toddlers for autism spectrum disorder using an Arabic validated version of M-CHAT; report of a community-based study (Stage I). European Psychiatry. 2016;34:43–8. doi: http://dx.doi.org/10.1016/j.eurpsy.2016.01.2421. X-126928345
5769 Mohammad-Rezazadeh I, Frohlich J, Loo SK, . Brain connectivity in autism spectrum disorder. Curr Opin Neurol. 2016 Apr;29(2):137–47. doi: 10.1097/wco.0000000000000301. X-126910484
5770 Mohr-Jensen C, Koch SV, Lauritsen MB, . The validity and reliability of the diagnosis of hyperkinetic disorders in the Danish Psychiatric Central Research Registry. European Psychiatry. 2016;35:16–24. doi: http://dx.doi.org/10.1016/j.eurpsy.2016.01.2427. X-127061373
5771 Momen S. Special care dentistry: Treating autistic children. Br Dent J. 2016 Feb 12;220(3):89. doi: 10.1038/sj.bdj.2016.68. X-1
5772 Montagna MT, Cristina ML, Giglio OD, . Serological and molecular identification of Legionella spp. isolated from water and surrounding air samples in Italian healthcare facilities. Environ Res. 2016 Apr;146:47–50. doi: 10.1016/j.envres.2015.12.015. X-126717079
5773 Monteiro SA, Dempsey J, Broton S, . Early intervention before autism diagnosis in children referred to a regional autism clinic. Journal of Developmental and Behavioral Pediatrics. 2016;37(1):15–9. doi: http://dx.doi.org/10.1097/DBP.0000000000000241. X-126647354
5774 Monyak RE, Emerson D, Schoenfeld BP, . Insulin signaling misregulation underlies circadian and cognitive deficits in a Drosophila fragile X model. Mol Psychiatry. 2016 Apr 19 doi: 10.1038/mp.2016.51. X-1
5775 Moore RD, Pindus DM, Raine LB, . The persistent influence of concussion on attention, executive control and neuroelectric function in preadolescent children. International Journal of Psychophysiology. 2016;99:85–95. doi: http://dx.doi.org/10.1016/j.ijpsycho.2015.11.010. X-126608697
5776 Moos WH, Faller DV, Harpp DN, . Microbiota and Neurological Disorders: A Gut Feeling. Biores Open Access. 2016;5(1):137–45. doi: 10.1089/biores.2016.0010. X-127274912
5777 Moraru C-A, Gomez J-C, McGuigan N. Developmental changes in the influence of conventional and instrumental cues on over-imitation in 3- to 6-year-old children. Journal of Experimental Child Psychology. 2016;145:34–47. doi: http://dx.doi.org/10.1016/j.jecp.2015.11.017. X-126774258
5778 Morava E, Tiemes V, Tiel C, . ALG6-CDG: a recognizable phenotype with epilepsy, proximal muscle weakness, ataxia and behavioral and limb anomalies. J Inherit Metab Dis. 2016 Jun 10 doi: 10.1007/s10545-016-9945-x. X-1
5779 Moreau PE, Ferrero E, Riouallon G, . Radiologic adjacent segment degeneration 2 years after lumbar fusion for degenerative spondylolisthesis. Orthop Traumatol Surg Res. 2016 Jun 1 doi: 10.1016/j.otsr.2016.03.012. X-1
5780 Moreira ES, Silva IMW, Lourenço N, . Detection of small copy number variations (CNVs) in autism spectrum disorder (ASD) by custom array comparative genomic hybridization (aCGH). Research in Autism Spectrum Disorders. 2016;23:145–51. doi: http://dx.doi.org/10.1016/j.rasd.2015.12.012. X-1
5781 Morett LM, O’Hearn K, Luna B, . Altered gesture and speech production in ASD detract from in-person communicative quality. Journal of Autism and Developmental Disorders. 2016;46(3):998–1012. doi: http://dx.doi.org/10.1007/s10803-015-2645-9. X-126520147
5782 Morris G, Berk M, Carvalho A, . The Role of the Microbial Metabolites Including Tryptophan Catabolites and Short Chain Fatty Acids in the Pathophysiology of Immune-Inflammatory and Neuroimmune Disease. Mol Neurobiol. 2016 Jun 27 doi: 10.1007/s12035-016-0004-2. X-1
5783 Mostafa GA, Bjorklund G, Urbina MA, . The positive association between elevated blood lead levels and brain-specific autoantibodies in autistic children from low lead-polluted areas. Metab Brain Dis. 2016 Jun 1 doi: 10.1007/s11011-016-9836-8. X-1
5784 Mostafa GA, Bjorklund G, Urbina MA, . The levels of blood mercury and inflammatory-related neuropeptides in the serum are correlated in children with autism spectrum disorder. Metab Brain Dis. 2016 Jun;31(3):593–9. doi: 10.1007/s11011-015-9784-8. X-126738726
5785 Mostafavi M, Hardy P, Arnold LE. Varenicline in Autism: Theory and Case Report of Clinical and Biochemical Changes. J Child Adolesc Psychopharmacol. 2016 Apr 28 doi: 10.1089/cap.2015.0230. X-1
5786 Mouga S, Cafe C, Almeida J, . Intellectual Profiles in the Autism Spectrum and Other Neurodevelopmental Disorders. J Autism Dev Disord. 2016 Jun 16 doi: 10.1007/s10803-016-2838-x. X-1
5787 Moulton E, Barton M, Robins DL, . Early characteristics of children with ASD who demonstrate optimal progress between age two and four. Journal of Autism and Developmental Disorders. 2016;46(6):2160–73. doi: http://dx.doi.org/10.1007/s10803-016-2745-1. X-126895327
5788 Mouridsen SE, Rich B, Isager T. Risk of cancer in adult people diagnosed with infantile autism in childhood: A longitudinal case control study based on hospital discharge diagnoses. Research in Autism Spectrum Disorders. 2016;23:203–9. doi: http://dx.doi.org/10.1016/j.rasd.2015.12.010. X-1
5789 Mucke HA. From Psychiatry to Flower Power and Back Again: The Amazing Story of Lysergic Acid Diethylamide. Assay Drug Dev Technol. 2016 Jul 8 doi: 10.1089/adt.2016.747. X-1
5790 Mulhern T, Lydon S, Healy O, . A systematic review and evaluation of procedures for the induction of speech among persons with developmental disabilities. Dev Neurorehabil. 2016 Apr 8:1–21. doi: 10.3109/17518423.2016.1150360. X-1, X-2
5791 Muller E, Cannon LR, Kornblum C, . Description and Preliminary Evaluation of a Curriculum for Teaching Conversational Skills to Children With High-Functioning Autism and Other Social Cognition Challenges. Lang Speech Hear Serv Sch. 2016 Jun 8:1–18. doi: 10.1044/2016_lshss-15-0042. X-1
5792 Muller N, Baumeister S, Dziobek I, . Validation of the Movie for the Assessment of Social Cognition in Adolescents with ASD: Fixation Duration and Pupil Dilation as Predictors of Performance. J Autism Dev Disord. 2016 Jun 6 doi: 10.1007/s10803-016-2828-z. X-1
5793 Muller-Pinzler L, Krach S, Kramer UM, . The Social Neuroscience of Interpersonal Emotions. Curr Top Behav Neurosci. 2016 Mar 6 doi: 10.1007/7854_2016_437. X-1, X-2
5794 Munde V, Vlaskamp C, ter Haar A. Social-emotional instability in individuals with Rett syndrome: Parents’ experiences with second stage behaviour. Journal of Intellectual Disability Research. 2016;60(1):43–53. doi: http://dx.doi.org/10.1111/jir.12233. X-126497300
5795 Mundy P, Kim K, McIntyre N, . Brief report: Joint attention and information processing in children with higher functioning autism spectrum disorders. Journal of Autism and Developmental Disorders. 2016;46(7):2555–60. doi: http://dx.doi.org/10.1007/s10803-016-2785-6. X-1, X-327062035
5796 Muotri AR. The Human Model: Changing Focus on Autism Research. Biol Psychiatry. 2016 Apr 15;79(8):642–9. doi: 10.1016/j.biopsych.2015.03.012. X-125861701
5797 Murakami T, Nakazawa G, Horinouchi H, . Transcatheter closure of atrial septal defect protects from pulmonary edema: septal occluder device gradually reduces LR shunt. Heart Vessels. 2016 Jun 17 doi: 10.1007/s00380-016-0863-5. X-1
5798 Murala J, Sassalos P, Si MS. ‘Near death’ thromboembolic episode following device closure of atrial septal defect. Interact Cardiovasc Thorac Surg. 2016 May 14 doi: 10.1093/icvts/ivw145. X-1
5799 Murphy CM, Wilson CE, Robertson DM, . Autism spectrum disorder in adults: diagnosis, management, and health services development. Neuropsychiatr Dis Treat. 2016;12:1669–86. doi: 10.2147/ndt.s65455. X-127462160
5800 Murphy J, Zlomke KR. A behavioral parent-training intervention for a child with avoidant/restrictive food intake disorder. Clinical Practice in Pediatric Psychology. 2016;4(1):23–34. doi: http://dx.doi.org/10.1037/cpp0000128. X-1
5801 Murza KA, Schwartz JB, Hahs-Vaughn DL, . Joint attention interventions for children with autism spectrum disorder: A systematic review and meta-analysis. International Journal of Language & Communication Disorders. 2016;51(3):236–51. doi: http://dx.doi.org/10.1111/1460-6984.12212. X-226952136
5802 Muscogiuri G, Altieri B, Annweiler C, . Vitamin D and chronic diseases: the current state of the art. Arch Toxicol. 2016 Jul 18 doi: 10.1007/s00204-016-1804-x. X-1
5803 Muskat B, Greenblatt A, Nicholas DB, . Parent and health care provider perspectives related to disclosure of autism spectrum disorder in pediatric emergency departments. Autism. 2016 Feb 5 doi: 10.1177/1362361315621520. X-1
5804 Mussap M, Noto A, Fanos V. Metabolomics of autism spectrum disorders: early insights regarding mammalian-microbial cometabolites. Expert Rev Mol Diagn. 2016 Jun 30:1–13. doi: 10.1080/14737159.2016.1202765. X-1
5805 Muszkat D, Polanczyk GV, Dias TG, . Transcranial Direct Current Stimulation in Child and Adolescent Psychiatry. J Child Adolesc Psychopharmacol. 2016 Mar 30 doi: 10.1089/cap.2015.0172. X-2, X-3
5806 Muzio L, Brambilla V, Calcaterra L, . Increased neuroplasticity and hippocampal microglia activation in a mice model of rapid antidepressant treatment. Behav Brain Res. 2016 Sep 15;311:392–402. doi: 10.1016/j.bbr.2016.05.063. X-127265783
5807 Mychasiuk R, Rho JM. Genetic modifications associated with ketogenic diet treatment in the BTBRT+Tf/J mouse model of autism spectrum disorder. Autism Res. 2016 Aug 16 doi: 10.1002/aur.1682. X-1
5808 Nader A-M, Courchesne V, Dawson M, . Does WISC-IV underestimate the intelligence of autistic children? Journal of Autism and Developmental Disorders. 2016;46(5):1582–9. doi: http://dx.doi.org/10.1007/s10803-014-2270-z. X-125308198
5809 Nadim WD, Simion V, Benedetti H, . MicroRNAs in Neurocognitive Dysfunctions: New Molecular Targets for Pharmacological Treatments? Curr Neuropharmacol. 2016 Jul 8. X-1
5810 Nagra MK, White R, Appiah A, . Intensive Interaction Training for Paid Carers: ‘Looking, Looking and Find Out When They Want to Relate to You’. J Appl Res Intellect Disabil. 2016 Jun 8 doi: 10.1111/jar.12259. X-1
5811 Nahum Sacks K, Friger M, Shoham-Vardi I, . Prenatal exposure to gestational diabetes mellitus as an independent risk factor for long-term neuropsychiatric morbidity of the offspring. Am J Obstet Gynecol. 2016 Mar 24 doi: 10.1016/j.ajog.2016.03.030. X-1
5812 Naigles LR, Cheng M, Rattansone NX, . “You’re telling me!” The Prevalence and Predictors of Pronoun Reversals in Children with Autism Spectrum Disorders and Typical Development. Res Autism Spectr Disord. 2016 Jul;27:11–20. doi: 10.1016/j.rasd.2016.03.008. X-127103941
5813 Nakagawa Y, Chiba K. Involvement of neuroinflammation during brain development in social cognitive deficits in autism spectrum disorder and schizophrenia. J Pharmacol Exp Ther. 2016 Jul 6 doi: 10.1124/jpet.116.234476. X-1
5814 Napoli E, Song G, Wong S, . Altered Bioenergetics in Primary Dermal Fibroblasts from Adult Carriers of the FMR1 Premutation Before the Onset of the Neurodegenerative Disease Fragile X-Associated Tremor/Ataxia Syndrome. Cerebellum. 2016 Apr 18 doi: 10.1007/s12311-016-0779-8. X-1
5815 Narita S, Nagahori K, Nishizawa D, . Association between AUTS2 haplotypes and alcohol dependence in a Japanese population. Acta Neuropsychiatr. 2016 Aug;28(4):214–20. doi: 10.1017/neu.2015.70. X-126763194
5816 Nassif M, Abdelghani M, Bouma BJ, . Historical developments of atrial septal defect closure devices: what we learn from the past. Expert Rev Med Devices. 2016 Jun;13(6):555–68. doi: 10.1080/17434440.2016.1182860. X-127112301
5817 Navon D, Eyal G. Looping Genomes: Diagnostic Change and the Genetic Makeup of the Autism Population. Ajs. 2016 Mar;121(5):1416–71. X-127092389
5818 Navot N, Jorgenson AG, Vander Stoep A, . Family planning and family vision in mothers after diagnosis of a child with autism spectrum disorder. Autism. 2016 Jul;20(5):605–15. doi: 10.1177/1362361315602134. X-126395237
5819 Nebel MB, Eloyan A, Nettles CA, . Intrinsic visual-motor synchrony correlates with social deficits in autism. Biological Psychiatry. 2016;79(8):633–41. doi: http://dx.doi.org/10.1016/j.biopsych.2015.08.029. X-126543004
5820 Neely KA, Mohanty S, Schmitt LM, . Motor Memory Deficits Contribute to Motor Impairments in Autism Spectrum Disorder. J Autism Dev Disord. 2016 May 7 doi: 10.1007/s10803-016-2806-5. X-1
5821 Neil L, Cappagli G, Karaminis T, . Recognizing the same face in different contexts: Testing within-person face recognition in typical development and in autism. Journal of Experimental Child Psychology. 2016;143:139–53. doi: http://dx.doi.org/10.1016/j.jecp.2015.09.029. X-126615971
5822 Neil L, Olsson NC, Pellicano E. The Relationship Between Intolerance of Uncertainty, Sensory Sensitivities, and Anxiety in Autistic and Typically Developing Children. J Autism Dev Disord. 2016 Jun;46(6):1962–73. doi: 10.1007/s10803-016-2721-9. X-126864157
5823 Nelson AT, Lopata C, Volker MA, . Exploratory Factor Analysis of SRS-2 Teacher Ratings for Youth with ASD. J Autism Dev Disord. 2016 Jun 22 doi: 10.1007/s10803-016-2822-5. X-1
5824 Nestor MW, Phillips AW, Artimovich E, . Human Inducible Pluripotent Stem Cells and Autism Spectrum Disorder: Emerging Technologies. Autism Res. 2016 May;9(5):513–35. doi: 10.1002/aur.1570. X-126426199
5825 Nesvag R, Hartz I, Bramness JG, . Mental disorder diagnoses among children and adolescents who use antipsychotic drugs. Eur Neuropsychopharmacol. 2016 Jul 21 doi: 10.1016/j.euroneuro.2016.07.001. X-1
5826 Neuhaus E, Jones EJH, Barnes K, . The relationship between early neural responses to emotional faces at age 3 and later autism and anxiety symptoms in adolescents with autism. Journal of Autism and Developmental Disorders. 2016;46(7):2450–63. doi: http://dx.doi.org/10.1007/s10803-016-2780-y. X-127055415
5827 Neuhaus E, Kresse A, Faja S, . Face processing among twins with and without autism: Social correlates and twin concordance. Social Cognitive and Affective Neuroscience. 2016;11(1):44–54. doi: http://dx.doi.org/10.1093/scan/nsv085. X-126137974
5828 Neumann ID, Slattery DA. Oxytocin in General Anxiety and Social Fear: A Translational Approach. Biol Psychiatry. 2016 Feb 1;79(3):213–21. doi: 10.1016/j.biopsych.2015.06.004. X-126208744
5829 Newbigin A, Uljarevic M, Vivanti G, . Brief Report: Empathic Responsiveness of High Functioning Children with Autism to Expressed and Anticipated Distress. J Autism Dev Disord. 2016 Jul 19 doi: 10.1007/s10803-016-2862-x. X-1
5830 Newbutt N, Sung C, Kuo HJ, . Brief Report: A Pilot Study of the Use of a Virtual Reality Headset in Autism Populations. J Autism Dev Disord. 2016 Jun 7 doi: 10.1007/s10803-016-2830-5. X-1
5831 Newhouse-Oisten MK, Kestner KM, Frieder JE. An evaluation of modified exposure therapy for a child diagnosed with obsessive compulsive disorder and pervasive developmental disorder–not otherwise specified. Behavior Analysis: Research and Practice. 2016;16(3):147–55. doi: http://dx.doi.org/10.1037/bar0000048. X-1, X-3, X-4
5832 Newschaffer CJ, Schriver E, Berrigan L, . Development and validation of a streamlined autism case confirmation approach for use in epidemiologic risk factor research in prospective cohorts. Autism Res. 2016 Aug 3 doi: 10.1002/aur.1659. X-1
5833 Neymotin F, Nemzer LR. Linking autism and epilepsy. Children’s Health Care. 2016;45(1):84–108. doi: http://dx.doi.org/10.1080/02739615.2014.979921. X-1
5834 Ngamsamut N, Hongkaew Y, Vanwong N, . 9-Hydroxyrisperidone-induced Hyperprolactinaemia in Thai Children and Adolescents with Autism Spectrum Disorder. Basic Clin Pharmacol Toxicol. 2016 Feb 16 doi: 10.1111/bcpt.12570. X-1
5835 Nguyen LS, Lepleux M, Makhlouf M, . Profiling olfactory stem cells from living patients identifies miRNAs relevant for autism pathophysiology. Mol Autism. 2016;7:1. doi: 10.1186/s13229-015-0064-6. X-126753090
5836 Nicholas DB, Zwaigenbaum L, Ing S, . “Live it to understand it”: The experiences of mothers of children with autism spectrum disorder. Qualitative Health Research. 2016;26(7):921–34. doi: http://dx.doi.org/10.1177/1049732315616622. X-126612886
5837 Nicholas DB, Zwaigenbaum L, Muskat B, . Experiences of emergency department care from the perspective of families in which a child has autism spectrum disorder. Soc Work Health Care. 2016 Jul;55(6):409–26. doi: 10.1080/00981389.2016.1178679. X-127315287
5838 Nicolaidis C, Raymaker D, McDonald K, . The Development and Evaluation of an Online Healthcare Toolkit for Autistic Adults and their Primary Care Providers. J Gen Intern Med. 2016 Jun 6 doi: 10.1007/s11606-016-3763-6. X-1
5839 Niinomi K, Asano M, Kadoma A, . Developing the “Skippu-Mama” program for mothers of children with autism spectrum disorder. Nurs Health Sci. 2016 Mar 4 doi: 10.1111/nhs.12264. X-1, X-3
5840 Nikolas MA, Elmore AL, Franzen L, . Risky bicycling behavior among youth with and without attention-deficit hyperactivity disorder. Journal of Child Psychology and Psychiatry. 2016;57(2):141–8. doi: http://dx.doi.org/10.1111/jcpp.12491. X-126610867
5841 Nikvarz N, Alaghband-Rad J, Tehrani-Doost M, . Comparing Efficacy and Side Effects of Memantine vs. Risperidone in the Treatment of Autistic Disorder. Pharmacopsychiatry. 2016 Jun 14 doi: 10.1055/s-0042-108449.
5842 Noel JP, De Niear MA, Stevenson R, . Atypical rapid audio-visual temporal recalibration in autism spectrum disorders. Autism Res. 2016 May 9 doi: 10.1002/aur.1633. X-1
5843 Nordahl CW, Mello M, Shen AM, . Methods for acquiring MRI data in children with autism spectrum disorder and intellectual impairment without the use of sedation. Journal of Neurodevelopmental Disorders. 2016;8 doi: http://dx.doi.org/10.1186/s11689-016-9154-9. X-126981159
5844 Nordahl-Hansen A, Fletcher-Watson S, McConachie H, . Relations between specific and global outcome measures in a social-communication intervention for children with autism spectrum disorder. Research in Autism Spectrum Disorders. 2016;29–30:19–29. doi: http://dx.doi.org/10.1016/j.rasd.2016.05.005. X-1
5845 Nordgren PM. F0, F0 range and duration of utterances—Longitudinal single-subject studies of prosody in two Swedish children with ASC. Clinical Linguistics & Phonetics. 2016;30(1):29–48. doi: http://dx.doi.org/10.3109/02699206.2015.1098728. X-1, X-3, X-426645486
5846 Nordt M, Hoehl S, Weigelt S. The use of repetition suppression paradigms in developmental cognitive neuroscience. Cortex: A Journal Devoted to the Study of the Nervous System and Behavior. 2016;80:61–75. doi: http://dx.doi.org/10.1016/j.cortex.2016.04.002. X-127161033
5847 Norkett R, Modi S, Birsa N, . DISC1-dependent Regulation of Mitochondrial Dynamics Controls the Morphogenesis of Complex Neuronal Dendrites. J Biol Chem. 2016 Jan 8;291(2):613–29. doi: 10.1074/jbc.M115.699447. X-126553875
5848 Noroozi R, Taheri M, Movafagh A, . Glutamate receptor, metabotropic 7 (GRM7) gene variations and susceptibility to autism: A case-control study. Autism Res. 2016 Jun 17 doi: 10.1002/aur.1640. X-1
5849 Notwell JH, Heavner WE, Fazel Darbandi S, . TBR1 regulates autism risk genes in the developing neocortex. Genome Res. 2016 Jun 20 doi: 10.1101/gr.203612.115. X-1
5850 Nunes DRP, Araújo ER, Walter E, . Augmenting caregiver responsiveness: An intervention proposal for youngsters with autism in Brazil. Early Childhood Education Journal. 2016;44(1):39–49. doi: http://dx.doi.org/10.1007/s10643-014-0677-y. X-3, X-4
5851 Nwaobi SE, Cuddapah VA, Patterson KC, . The role of glial-specific Kir4.1 in normal and pathological states of the CNS. Acta Neuropathol. 2016 Jul;132(1):1–21. doi: 10.1007/s00401-016-1553-1. X-126961251
5852 O’Neill S, Thornton V, Marks DJ, . Early language mediates the relations between preschool inattention and school-age reading achievement. Neuropsychology. 2016;30(4):398–404. doi: http://dx.doi.org/10.1037/neu0000247. X-126569031
5853 O’Nions E, Gould J, Christie P, . Identifying features of ‘pathological demand avoidance’ using the Diagnostic Interview for Social and Communication Disorders (DISCO). European Child & Adolescent Psychiatry. 2016;25(4):407–19. doi: http://dx.doi.org/10.1007/s00787-015-0740-2. X-126224583
5854 Oaks AW, Zamarbide M, Tambunan DE, . Cc2d1a Loss of Function Disrupts Functional and Morphological Development in Forebrain Neurons Leading to Cognitive and Social Deficits. Cereb Cortex. 2016 Jan 29 doi: 10.1093/cercor/bhw009. X-1
5855 Obeid I, Boissiere L, Yilgor C, . Global tilt: a single parameter incorporating spinal and pelvic sagittal parameters and least affected by patient positioning. Eur Spine J. 2016 Jun 20 doi: 10.1007/s00586-016-4649-3. X-1
5856 Obel C, Zhu JL, Olsen J, . The risk of attention deficit hyperactivity disorder in children exposed to maternal smoking during pregnancy—A reexamination using a sibling design. Journal of Child Psychology and Psychiatry. 2016;57(4):532–7. doi: http://dx.doi.org/10.1111/jcpp.12478. X-126511313
5857 Oberg AS, D’Onofrio BM, Rickert ME, . Association of Labor Induction With Offspring Risk of Autism Spectrum Disorders. JAMA Pediatr. 2016 Jul 25:e160965. doi: 10.1001/jamapediatrics.2016.0965. X-1
5858 Oberman LM, Enticott PG, Casanova MF, . Transcranial magnetic stimulation in autism spectrum disorder: Challenges, promise, and roadmap for future research. Autism Res. 2016 Feb;9(2):184–203. doi: 10.1002/aur.1567. X-1, X-226536383
5859 Oberman LM, Ifert-Miller F, Najib U, . Abnormal Mechanisms of Plasticity and Metaplasticity in Autism Spectrum Disorders and Fragile X Syndrome. J Child Adolesc Psychopharmacol. 2016 May 24 doi: 10.1089/cap.2015.0166. X-1
5860 O’Byrne ML, Gillespie MJ, Kennedy KF, . The influence of deficient retro-aortic rim on technical success and early adverse events following device closure of secundum atrial septal defects: An Analysis of the IMPACT Registry(R). Catheter Cardiovasc Interv. 2016 May 18 doi: 10.1002/ccd.26585. X-1
5861 Ochi M, Kimura K, Kanda A, . Physicochemical and Pharmacokinetic Characterization of Amorphous Solid Dispersion of Meloxicam with Enhanced Dissolution Property and Storage Stability. AAPS PharmSciTech. 2016 Aug;17(4):932–9. doi: 10.1208/s12249-015-0422-x. X-127435198
5862 O’Connor E. The use of ‘Circle of Friends’ strategy to improve social interactions and social acceptance: A case study of a child with Asperger’s Syndrome and other associated needs. Support for Learning. 2016;31(2):138–47. doi: http://dx.doi.org/10.1111/1467-9604.12122. X-3, X-4
5863 Odent MR. The future of neonatal BCG. Med Hypotheses. 2016 Jun;91:34–6. doi: 10.1016/j.mehy.2016.04.010. X-127142139
5864 Odom SL. Review of Neurotribes: The legacy of autism and the future of neurodiversity. Journal of Autism and Developmental Disorders. 2016;46(5):1885–6. doi: http://dx.doi.org/10.1007/s10803-016-2726-4. X-1, X-2
5865 Oe S, Yamato Y, Togawa D, . Preoperative T1 Slope More Than 40 degrees as a Risk Factor of Correction Loss in Patients with Adult Spinal Deformity. Spine (Phila Pa 1976). 2016 Mar 26 doi: 10.1097/brs.0000000000001578. X-1
5866 Oerlemans AM, Burmanje MJ, Franke B, . Identifying unique versus shared pre- and perinatal risk factors for ASD and ADHD using a simplex-multiplex stratification. Journal of Abnormal Child Psychology. 2016;44(5):923–35. doi: http://dx.doi.org/10.1007/s10802-015-0081-0. X-126466830
5867 Oerlemans AM, Hartman CA, Franke B, . Does the cognitive architecture of simplex and multiplex ASD families differ? Journal of Autism and Developmental Disorders. 2016;46(2):489–501. doi: http://dx.doi.org/10.1007/s10803-015-2572-9. X-126340958
5868 Ogden KK, Ozkan ED, Rumbaugh G. Prioritizing the development of mouse models for childhood brain disorders. Neuropharmacology. 2016 Jan;100:2–16. doi: 10.1016/j.neuropharm.2015.07.029. X-126231830
5869 Ogg JA, Bateman L, Dedrick RF, . The relationship between life satisfaction and ADHD symptoms in middle school students: Using a bifactor model. Journal of Attention Disorders. 2016;20(5):390–9. doi: http://dx.doi.org/10.1177/1087054714521292. X-124514584
5870 O’Hare A, Bremner L. Management of developmental speech and language disorders: Part 1. Arch Dis Child. 2016 Mar;101(3):272–7. doi: 10.1136/archdischild-2014-307394. X-126208514
5871 Oien RA, Siper P, Kolevzon A, . Detecting Autism Spectrum Disorder in Children With ADHD and Social Disability. J Atten Disord. 2016 Apr 13 doi: 10.1177/1087054716642518. X-1
5872 Oja L, Huotilainen M, Nikkanen E, . Behavioral and electrophysiological indicators of auditory distractibility in children with ADHD and comorbid ODD. Brain Research. 2016;1632:42–50. doi: http://dx.doi.org/10.1016/j.brainres.2015.12.003. X-126688114
5873 Olçay-Gül S, Tekin-Iftar E. Family generated and delivered social story intervention: Acquisition, maintenance, and generalization of social skills in youths with ASD. Education and Training in Autism and Developmental Disabilities. 2016;51(1):67–78. X-1, X-3
5874 Olexova L, Stefanik P, Krskova L. Increased anxiety-like behaviour and altered GABAergic system in the amygdala and cerebellum of VPA rats-An animal model of autism. Neurosci Lett. 2016 Jun 25 doi: 10.1016/j.neulet.2016.06.035. X-1
5875 Olivito G, Clausi S, Laghi F, . Resting-State Functional Connectivity Changes Between Dentate Nucleus and Cortical Social Brain Regions in Autism Spectrum Disorders. Cerebellum. 2016 Jun 1 doi: 10.1007/s12311-016-0795-8. X-1
5876 Olmsted D, Blaxill M. Leo Kanner’s mention of 1938 in his report on autism refers to his first patient. Journal of Autism and Developmental Disorders. 2016;46(1):340–1. doi: http://dx.doi.org/10.1007/s10803-015-2541-3. X-126231203
5877 O’Neill KR, Wilson RJ, Burns KM, . Anterior Cervical Discectomy and Fusion for Adjacent Segment Disease: Clinical Outcomes and Cost Utility of Surgical Intervention. Clin Spine Surg. 2016 Jul;29(6):234–41. doi: 10.1097/BSD.0b013e31828ffc54. X-127137162
5878 Ooi KL, Ong YS, Jacob SA, . A meta-synthesis on parenting a child with autism. Neuropsychiatric Disease and Treatment. 2016;12. X-1, X-2, X-3
5879 Ooi YP, Weng S-J, Magiati I, . Factors influencing agreement between parent and child reports of anxiety symptoms among children with high-functioning Autism Spectrum Disorders. Journal of Developmental and Physical Disabilities. 2016;28(3):407–24. doi: http://dx.doi.org/10.1007/s10882-016-9481-5. X-1
5880 Orefice LL, Zimmerman AL, Chirila AM, . Peripheral Mechanosensory Neuron Dysfunction Underlies Tactile and Behavioral Deficits in Mouse Models of ASDs. Cell. 2016 Jun 8 doi: 10.1016/j.cell.2016.05.033. X-1
5881 Ormond DR, Albert L, Jr., Das K. Polyetheretherketone (PEEK) Rods in Lumbar Spine Degenerative Disease: A Case Series. Clin Spine Surg. 2016 Aug;29(7):E371–5. doi: 10.1097/BSD.0b013e318277cb9b. X-123075859
5882 O’Shea KS, McInnis MG. Neurodevelopmental origins of bipolar disorder: iPSC models. Mol Cell Neurosci. 2016 Jun;73:63–83. doi: 10.1016/j.mcn.2015.11.006. X-126608002
5883 Oswald TM, Winter-Messiers MA, Gibson B, . Sex differences in internalizing problems during adolescence in autism spectrum disorder. Journal of Autism and Developmental Disorders. 2016;46(2):624–36. doi: http://dx.doi.org/10.1007/s10803-015-2608-1. X-126438640
5884 Ottley JR, Ferron JM, Hanline MF. Explaining variance and identifying predictors of children’s communication via a multilevel model of single-case design research. Developmental Neurorehabilitation. 2016;19(3):197–202. X-125825922
5885 Ottosen C, Petersen L, Larsen JT, . Gender differences in associations between attention-deficit/hyperactivity disorder and substance use disorder. Journal of the American Academy of Child & Adolescent Psychiatry. 2016;55(3):227–34. doi: http://dx.doi.org/10.1016/j.jaac.2015.12.010. X-126903256
5886 Ouyang M, Cheng H, Mishra V, . Atypical age-dependent effects of autism on white matter microstructure in children of 2–7 years. Human Brain Mapping. 2016;37(2):819–32. doi: http://dx.doi.org/10.1002/hbm.23073. X-126663516
5887 Ouyang M, Jeon T, Mishra V, . Global and regional cortical connectivity maturation index (CCMI) of developmental human brain with quantification of short-range association tracts. Proc SPIE Int Soc Opt Eng. 2016 Feb 27;9788 doi: 10.1117/12.2218029. X-1, X-3
5888 Overgaard KR, Aase H, Torgersen S, . Co-occurrence of ADHD and anxiety in preschool children. Journal of Attention Disorders. 2016;20(7):573–80. doi: http://dx.doi.org/10.1177/1087054712463063. X-123160487
5889 Oxelgren UW, Myrelid A, Anneren G, . Prevalence of autism and attention-deficit-hyperactivity disorder in Down syndrome: a population-based study. Dev Med Child Neurol. 2016 Aug 9 doi: 10.1111/dmcn.13217. X-1
5890 Özçalışkan Ş, Adamson LB, Dimitrova N. Early deictic but not other gestures predict later vocabulary in both typical development and autism. Autism. 2016;20(6):754–63. doi: http://dx.doi.org/10.1177/1362361315605921. X-1, X-326503989
5891 Ozsivadjian A, Hollocks MJ, Southcott J, . Anxious Imagery in Children With and Without Autism Spectrum Disorder: An Investigation into Occurrence, Content, Features and Implications for Therapy. J Autism Dev Disord. 2016 Jun 21 doi: 10.1007/s10803-016-2840-3. X-1
5892 Ozturk Y, Vivanti G, Uljarevic M, . Treatment-related changes in children’s communication impact on maternal satisfaction and psychological distress. Res Dev Disabil. 2016 Sep;56:128–38. doi: 10.1016/j.ridd.2016.05.021. X-127295207
5893 Paasch V, Leibowitz L, Accardo J, . Preparing children with autism spectrum disorders for overnight sleep studies: A case series. Clinical Practice in Pediatric Psychology. 2016;4(2):153–63. doi: http://dx.doi.org/10.1037/cpp0000139. X-1, X-3, X-4
5894 Page TF, Pelham WE, III, Fabiano GA, . Comparative cost analysis of sequential, adaptive, behavioral, pharmacological, and combined treatments for childhood ADHD. Journal of Clinical Child and Adolescent Psychology. 2016;45(4):416–27. doi: http://dx.doi.org/10.1080/15374416.2015.1055859. X-126808137
5895 Palm U, Segmiller FM, Epple AN, . Transcranial direct current stimulation in children and adolescents: a comprehensive review. J Neural Transm (Vienna). 2016 May 12 doi: 10.1007/s00702-016-1572-z. X-1
5896 Pan CC, Davis R, Nichols D, . Prevalence of overweight and obesity among students with intellectual disabilities in Taiwan: A secondary analysis. Res Dev Disabil. 2016 Jun–Jul;53–54:305–13. doi: 10.1016/j.ridd.2016.02.018. X-1
5897 Pan CY, Chu CH, Tsai CL, . The impacts of physical activity intervention on physical and cognitive outcomes in children with autism spectrum disorder. Autism. 2016 Apr 7 doi: 10.1177/1362361316633562. X-1
5898 Panchision DM. Concise Review: Progress and Challenges in Using Human Stem Cells for Biological and Therapeutics Discovery: Neuropsychiatric Disorders. Stem Cells. 2016 Mar;34(3):523–36. doi: 10.1002/stem.2295. X-126840228
5899 Pandya NJ, Klaassen RV, van der Schors RC, . Group 1 metabotropic glutamate receptors 1 and 5 form a protein complex in mouse hippocampus and cortex. Proteomics. 2016 Jul 9 doi: 10.1002/pmic.201500400. X-1
5900 Pantelis PC, Kennedy DP. Estimation of the prevalence of autism spectrum disorder in South Korea, revisited. Autism. 2016;20(5):517–27. doi: http://dx.doi.org/10.1177/1362361315592378. X-126122467
5901 Papatola KJ, Lustig SL. Navigating a managed care peer review: Guidance for clinicians using applied behavior analysis in the treatment of children on the autism spectrum. Behavior Analysis in Practice. 2016;9(2):135–45. doi: http://dx.doi.org/10.1007/s40617-016-0120-5. X-127606250
5902 Park HK, Shin HJ, Park YH, . The importance of preoperative oxygen saturation as a predictor of pulmonary arterial hypertension after surgery of atrial septal defects. Interact Cardiovasc Thorac Surg. 2016 May 24 doi: 10.1093/icvts/ivw162. X-1
5903 Park P, Okonkwo DO, Nguyen S, . Can a Minimal Clinically Important Difference Be Achieved in Elderly Patients with Adult Spinal Deformity Who Undergo Minimally Invasive Spinal Surgery? World Neurosurg. 2016 Feb;86:168–72. doi: 10.1016/j.wneu.2015.09.072. X-126431736
5904 Park P, Wang MY, Nguyen S, . Comparison of Complications and Clinical and Radiographic Outcomes Between Nonobese and Obese Patients with Adult Spinal Deformity Undergoing Minimally Invasive Surgery. World Neurosurg. 2016 Mar;87:55–60. doi: 10.1016/j.wneu.2015.12.024. X-126724613
5905 Park SJ, Lee CS, Chung SS, . Different Risk Factors of Proximal Junctional Kyphosis and Proximal Junctional Failure Following Long Instrumented Fusion to the Sacrum for Adult Spinal Deformity: Survivorship Analysis of 160 Patients. Neurosurgery. 2016 Apr 8 doi: 10.1227/neu.0000000000001240. X-1
5906 Park SY, Cervesi C, Galling B, . Antipsychotic Use Trends in Youth With Autism Spectrum Disorder and/or Intellectual Disability: A Meta-Analysis. J Am Acad Child Adolesc Psychiatry. 2016 Jun;55(6):456–68.e4. doi: 10.1016/j.jaac.2016.03.012. X-127238064
5907 Parker A, Corkum P. ADHD diagnosis: As simple as administering a questionnaire or a complex diagnostic process? Journal of Attention Disorders. 2016;20(6):478–86. doi: http://dx.doi.org/10.1177/1087054713495736. X-123887860
5908 Parker CH. TRUST A v X AND OTHERS: THE GHOST OF NIELSEN RETURNS? Med Law Rev. 2016 Spring;24(2):268–77. doi: 10.1093/medlaw/fwv047. X-127273919
5909 Pasco Fearon RM. Editorial: Looking beyond the horizon – innovation in child psychology and psychiatry. Journal of Child Psychology and Psychiatry. 2016;57(3):213–5. doi: http://dx.doi.org/10.1111/jcpp.12545. X-1, X-226889890
5910 Passias PG, Klineberg EO, Jalai CM, . Hospital Readmission within Two Years Following Adult Thoracolumbar Spinal Deformity Surgery: Prevalence, Predictors, and Effect on Patient-Derived Outcome Measures. Spine (Phila Pa 1976). 2016 Mar 8 doi: 10.1097/brs.0000000000001552. X-1
5911 Passias PG, Oh C, Jalai CM, . Predictive Model for Cervical Alignment and Malalignment Following Surgical Correction of Adult Spinal Deformity. Spine (Phila Pa 1976). 2016 Apr 19 doi: 10.1097/brs.0000000000001640. X-1
5912 Pastor-Cerezuela G, Fernández-Andrés M-I, Feo-Álvarez M, . Semantic verbal fluency in children with and without Autism Spectrum Disorder: Relationship with chronological age and IQ. Frontiers in Psychology. 2016;7. X-1
5913 Patak J, Zhang-James Y, Faraone SV. Endosomal system genetics and autism spectrum disorders: A literature review. Neurosci Biobehav Rev. 2016 Jun;65:95–112. doi: 10.1016/j.neubiorev.2016.03.022. X-127048963
5914 Patel I, Erickson SR, Caldwell CH, . Predictors of medication adherence and persistence in Medicaid enrollees with developmental disabilities and type 2 diabetes. Res Social Adm Pharm. 2016 Jul–Aug;12(4):592–603. doi: 10.1016/j.sapharm.2015.09.008. X-126522400
5915 Patel S, Day TN, Jones N, . Association between anger rumination and autism symptom severity, depression symptoms, aggression, and general dysregulation in adolescents with autism spectrum disorder. Autism. 2016 Apr 19 doi: 10.1177/1362361316633566. X-1
5916 Patriquin MA, DeRamus T, Libero LE, . Neuroanatomical and neurofunctional markers of social cognition in autism spectrum disorder. Hum Brain Mapp. 2016 Jun 22 doi: 10.1002/hbm.23288. X-1
5917 Patros CHG, Alderson RM, Kasper LJ, . Choice-impulsivity in children and adolescents with attention-deficit/hyperactivity disorder (ADHD): A meta-analytic review. Clinical Psychology Review. 2016;43:162–74. doi: http://dx.doi.org/10.1016/j.cpr.2015.11.001. X-126602954
5918 Pawar J, Tayade A, Gangurde A, . Solubility and dissolution enhancement of efavirenz hot melt extruded amorphous solid dispersions using combination of polymeric blends: A QbD approach. Eur J Pharm Sci. 2016 Jun 10;88:37–49. doi: 10.1016/j.ejps.2016.04.001. X-127049050
5919 Paynter JM, Ferguson S, Fordyce K, . Utilisation of evidence-based practices by ASD early intervention service providers. Autism. 2016 Apr 18 doi: 10.1177/1362361316633032. X-1
5920 Pearson BL, Crawley JN, Eilam D, . Curiosity as an approach to ethoexperimental analysis: Behavioral neuroscience as seen by students and colleagues of Bob Blanchard. Neurosci Biobehav Rev. 2016 Mar 24 doi: 10.1016/j.neubiorev.2016.03.012. X-1
5921 Pearson BL, Simon JM, McCoy ES, . Identification of chemicals that mimic transcriptional changes associated with autism, brain aging and neurodegeneration. Nat Commun. 2016;7:11173. doi: 10.1038/ncomms11173. X-127029645
5922 Peckett H, MacCallum F, Knibbs J. Maternal experience of Lego Therapy in families with children with autism spectrum conditions: What is the impact on family relationships? Autism. 2016 Feb 5 doi: 10.1177/1362361315621054. X-1
5923 Pedapati EV, Gilbert DL, Erickson CA, . Abnormal Cortical Plasticity in Youth with Autism Spectrum Disorder: A Transcranial Magnetic Stimulation Case-Control Pilot Study. J Child Adolesc Psychopharmacol. 2016 Mar 23 doi: 10.1089/cap.2015.0183. X-1
5924 Peeters B, Noens I, Kuppens S, . Toilet training in children with a functional defecation disorder and concomitant symptoms of autism spectrum disorder. Research in Autism Spectrum Disorders. 2016;26:91–8. doi: http://dx.doi.org/10.1016/j.rasd.2016.02.009. X-1
5925 Pegado F, Vankrunkelsven H, Steyaert J, . Exploring the Use of Sensorial LTP/LTD-Like Stimulation to Modulate Human Performance for Complex Visual Stimuli. PLoS One. 2016;11(6):e0158312. doi: 10.1371/journal.pone.0158312. X-127341210
5926 Pelham WE, Jr., Fabiano GA, Waxmonsky JG, . Treatment sequencing for childhood ADHD: A multiple-randomization study of adaptive medication and behavioral interventions. Journal of Clinical Child and Adolescent Psychology. 2016;45(4):396–415. doi: http://dx.doi.org/10.1080/15374416.2015.1105138. X-126882332
5927 Pennisi P, Tonacci A, Tartarisco G, . Autism and social robotics: A systematic review. Autism Res. 2016 Feb;9(2):165–83. doi: 10.1002/aur.1527. X-226483270
5928 Peralta F, Fuentealba C, Fiedler J, . Prenatal valproate treatment produces autistic-like behavior and increases metabotropic glutamate receptor 1A-immunoreactivity in the hippocampus of juvenile rats. Mol Med Rep. 2016 Sep;14(3):2807–14. doi: 10.3892/mmr.2016.5529. X-127430241
5929 Perathoner S, Cordero-Maldonado ML, Crawford AD. Potential of zebrafish as a model for exploring the role of the amygdala in emotional memory and motivational behavior. J Neurosci Res. 2016 Jun;94(6):445–62. doi: 10.1002/jnr.23712. X-126833658
5930 Perera H, Jeewandara KC, Seneviratne S, . Outcome of Home-Based Early Intervention for Autism in Sri Lanka: Follow-Up of a Cohort and Comparison with a Nonintervention Group. Biomed Res Int. 2016;2016:3284087. doi: 10.1155/2016/3284087. X-127419131
5931 Perez-Pouchoulen M, Miquel M, Saft P, . Prenatal exposure to sodium valproate alters androgen receptor expression in the developing cerebellum in a region and age specific manner in male and female rats. Int J Dev Neurosci. 2016 Jul 14;53:46–52. doi: 10.1016/j.ijdevneu.2016.07.001. X-127423376
5932 Peschansky VJ, Pastori C, Zeier Z, . The long non-coding RNA FMR4 promotes proliferation of human neural precursor cells and epigenetic regulation of gene expression in trans. Mol Cell Neurosci. 2016 Mar 19;74:49–57. doi: 10.1016/j.mcn.2016.03.008. X-127001315
5933 Peters B. A model for enhancing social communication and interaction in everyday activities for primary school children with ASD. Journal of Research in Special Educational Needs. 2016;16(2):89–101. doi: http://dx.doi.org/10.1111/1471-3802.12059. X-1, X-3, X-4
5934 Peters S, Van Duijvenvoorde ACK, Koolschijn PCMP, . Longitudinal development of frontoparietal activity during feedback learning: Contributions of age, performance, working memory and cortical thickness. Developmental Cognitive Neuroscience. 2016;19:211–22. doi: http://dx.doi.org/10.1016/j.dcn.2016.04.004. X-127104668
5935 Peters SU, Byiers BJ, Symons FJ. Diurnal salivary cortisol and regression status in MECP2 duplication syndrome. Journal of Child Neurology. 2016;31(2):159–63. doi: http://dx.doi.org/10.1177/0883073815585577. X-125999300
5936 Peterson BT, Anderer P, Moreau A, . A novel actigraphy data analysis tool and its application to identifying the optimal threshold value in three subject populations. Physiol Meas. 2016 Jun 20;37(7):N49–n61. doi: 10.1088/0967-3334/37/7/n49. X-127319572
5937 Peterson C, Lerman DC, Nissen MA. Reinforcer choice as an antecedent versus consequence. Journal of Applied Behavior Analysis. 2016;49(2):286–93. doi: http://dx.doi.org/10.1002/jaba.284. X-1, X-3, X-426792252
5938 Peterson C, Slaughter V, Moore C, . Peer social skills and theory of mind in children with autism, deafness, or typical development. Developmental Psychology. 2016;52(1):46–57. doi: http://dx.doi.org/10.1037/a0039833. X-126524383
5939 Peterson KM, Piazza CC, Volkert VM. A comparison of a modified sequential oral sensory approach to an applied behavior-analytic approach in the treatment of food selectivity in children with autism spectrum disorders. J Appl Behav Anal. 2016 Jul 23 doi: 10.1002/jaba.332. X-1, X-4
5940 Petrina N, Carter M, Stephenson J, . Perceived friendship quality of children with autism spectrum disorder as compared to their peers in mixed and non-mixed dyads. Journal of Autism and Developmental Disorders. 2016;46(4):1334–43. doi: http://dx.doi.org/10.1007/s10803-015-2673-5. X-126659812
5941 Pham AV. Differentiating behavioral ratings of inattention, impulsivity, and hyperactivity in children: Effects on reading achievement. Journal of Attention Disorders. 2016;20(8):674–83. doi: http://dx.doi.org/10.1177/1087054712473833. X-123400214
5942 Phan P, Ploumis A, Hess K, . Evaluating the Extent of Clinical Variability Among Treatment Options for Patients With Adult Spinal Deformity. Clin Spine Surg. 2016 Jun 27 doi: 10.1097/bsd.0000000000000407. X-1
5943 Phillips D, Choleris E, Ervin KS, . Cage-induced stereotypic behaviour in laboratory mice covaries with nucleus accumbens FosB/DeltaFosB expression. Behav Brain Res. 2016 Mar 15;301:238–42. doi: 10.1016/j.bbr.2015.12.035. X-126731014
5944 Philpott-Robinson K, Lane AE, Harpster K. Sensory Features of Toddlers at Risk for Autism Spectrum Disorder. Am J Occup Ther. 2016 Jul–Aug;70(4):7004220010p1–8. doi: 10.5014/ajot.2016.019497. X-1
5945 Pickard KE, Kilgore AN, Ingersoll BR. Using Community Partnerships to Better Understand the Barriers to Using an Evidence-Based, Parent-Mediated Intervention for Autism Spectrum Disorder in a Medicaid System. Am J Community Psychol. 2016 Jun;57(3–4):391–403. doi: 10.1002/ajcp.12050. X-127216766
5946 Pickard KE, Wainer AL, Bailey KM, . A mixed-method evaluation of the feasibility and acceptability of a telehealth-based parent-mediated intervention for children with autism spectrum disorder. Autism. 2016 Feb 9 doi: 10.1177/1362361315614496. X-1
5947 Pierce K, Courchesne E, Bacon E. To Screen or Not to Screen Universally for Autism is not the Question: Why the Task Force Got It Wrong. J Pediatr. 2016 Jul 12 doi: 10.1016/j.jpeds.2016.06.004. X-1
5948 Pierce K, Marinero S, Hazin R, . Eye tracking reveals abnormal visual preference for geometric images as an early biomarker of an autism spectrum disorder subtype associated with increased symptom severity. Biological Psychiatry. 2016;79(8):657–66. doi: http://dx.doi.org/10.1016/j.biopsych.2015.03.032. X-125981170
5949 Pierucci JM. Mothers’ scaffolding techniques used during play in toddlers with autism spectrum disorder. Journal of Developmental and Physical Disabilities. 2016;28(2):217–35. doi: http://dx.doi.org/10.1007/s10882-015-9459-8. X-1
5950 Pietropaolo S, Crusio WE, D’Amato F R. Treatment Approaches in Rodent Models for Autism Spectrum Disorder. Curr Top Behav Neurosci. 2016 Feb 9 doi: 10.1007/7854_2015_433. X-1
5951 Piletic K, Kunej T. MicroRNA epigenetic signatures in human disease. Arch Toxicol. 2016 Aug 24 doi: 10.1007/s00204-016-1815-7. X-1
5952 Pinggera A, Striessnig J. Cav 1.3 (CACNA1D) L-type Ca2+ channel dysfunction in CNS disorders. J Physiol.. 2016 Feb 4 doi: 10.1113/jp270672. X-1
5953 Pini G, Congiu L, Benincasa A, . Illness Severity, Social and Cognitive Ability, and EEG Analysis of Ten Patients with Rett Syndrome Treated with Mecasermin (Recombinant Human IGF-1). Autism Res Treat. 2016;2016:5073078. doi: 10.1155/2016/5073078. X-126925263
5954 Pinto AM, Bianciardi L, Mencarelli MA, . Exome sequencing analysis in a pair of monozygotic twins re-evaluates the genetics behind their intellectual disability and reveals a CHD2 mutation. Brain & Development. 2016;38(6):590–6. doi: http://dx.doi.org/10.1016/j.braindev.2015.12.006. X-126754451
5955 Pinto R, Rijsdijk F, Ouellet-Morin I, . The aetiological association between the dynamics of cortisol productivity and ADHD. Journal of Neural Transmission. 2016;123(8):991–1000. doi: http://dx.doi.org/10.1007/s00702-016-1534-5. X-127106905
5956 Pinto R, Rijsdijk F, Ronald A, . The genetic overlap of attention-deficit/hyperactivity disorder and autistic-like traits: An investigation of individual symptom scales and cognitive markers. Journal of Abnormal Child Psychology. 2016;44(2):335–45. doi: http://dx.doi.org/10.1007/s10802-015-0037-4. X-126021462
5957 Pivovarciova A, Durdiakova J, Babinska K, . Testosterone and androgen receptor sensitivity in relation to hyperactivity symptoms in boys with Autism spectrum disorders. PLoS ONE. 2016;11(2). X-1
5958 Plaisance L, Lerman DC, Laudont C, . Inserting mastered targets during error correction when teaching skills to children with autism. Journal of Applied Behavior Analysis. 2016;49(2):251–64. doi: http://dx.doi.org/10.1002/jaba.292. X-1, X-3, X-426790395
5959 Plasschaert E, Van Eylen L, Descheemaeker MJ, . Executive functioning deficits in children with neurofibromatosis type 1: The influence of intellectual and social functioning. American Journal of Medical Genetics Part B: Neuropsychiatric Genetics. 2016;171(3):348–62. doi: http://dx.doi.org/10.1002/ajmg.b.32414. X-1
5960 Plavnick JB, Vitale FA. A comparison of vocal mand training strategies for children with autism spectrum disorders. Journal of Positive Behavior Interventions. 2016;18(1):52–62. doi: http://dx.doi.org/10.1177/1098300714548800. X-3, X-4
5961 Plesa Skwerer D, Jordan SE, Brukilacchio BH, . Comparing methods for assessing receptive language skills in minimally verbal children and adolescents with autism spectrum disorders. Autism. 2016;20(5):591–604. doi: http://dx.doi.org/10.1177/1362361315600146.x-1 26408635
5962 Pletz J, Sanchez-Bayo F, Tennekes HA. Dose-response analysis indicating time-dependent neurotoxicity caused by organic and inorganic mercury-Implications for toxic effects in the developing brain. Toxicology. 2016 Mar 10;347–349:1–5. doi: 10.1016/j.tox.2016.02.006. X-1
5963 Podlesnik CA, Jimenez-Gomez C. Contrafreeloading, reinforcement rate, and behavioral momentum. Behav Processes. 2016 Jul;128:24–8. doi: 10.1016/j.beproc.2016.03.022. X-127045696
5964 Polfuss M, Johnson N, Bonis SA, . Autism Spectrum Disorder and the Child’s Weight-Related Behaviors: A Parents’ Perspective. J Pediatr Nurs. 2016 Jun 20 doi: 10.1016/j.pedn.2016.05.006. X-1, X-4
5965 Politi Y, Pippel E, Licuco-Massouh AC, . Nano-channels in the spider fang for the transport of Zn ions to cross-link His-rich proteins pre-deposited in the cuticle matrix. Arthropod Struct Dev. 2016 Jun 18 doi: 10.1016/j.asd.2016.06.001. X-1
5966 Pollack B, Hojnoski R, DuPaul GJ, . Play behavior differences among preschoolers with ADHD: Impact of comorbid ODD and anxiety. Journal of Psychopathology and Behavioral Assessment. 2016;38(1):66–75. doi: http://dx.doi.org/10.1007/s10862-015-9497-7. X-1
5967 Polzin A, Dannenberg L, Sophia Popp V, . Antiplatelet effects of clopidogrel and aspirin after interventional patent foramen ovale/ atrium septum defect closure. Platelets. 2016 Jun;27(4):317–21. doi: 10.3109/09537104.2015.1096335. X-126556101
5968 Ponce P, Molina A, Grammatikou D. Design based on fuzzy signal detection theory for a semi-autonomous assisting robot in children autism therapy. Computers in Human Behavior. 2016;51(Part A):28–42. doi: http://dx.doi.org/10.1016/j.chb.2015.08.036. X-1
5969 Poon KK, Yang X. The student profile, service delivery model, and support practices of four early childhood intervention environments in Singapore. Asia Pacific Journal of Education. 2016;36(3):437–49. doi: http://dx.doi.org/10.1080/02188791.2014.940030. X-1
5970 Poopal AC, Schroeder LM, Horn PS, . Increased expression of the PI3K catalytic subunit p110delta underlies elevated S6 phosphorylation and protein synthesis in an individual with autism from a multiplex family. Mol Autism. 2016;7:3. doi: 10.1186/s13229-015-0066-4. X-126770665
5971 Popple B, Wall C, Flink L, . Brief Report: Remotely Delivered Video Modeling for Improving Oral Hygiene in Children with ASD: A Pilot Study. J Autism Dev Disord. 2016 Apr 22 doi: 10.1007/s10803-016-2795-4. X-1
5972 Portales-Casamar E, Lussier AA, Jones MJ, . DNA methylation signature of human fetal alcohol spectrum disorder. Epigenetics Chromatin. 2016;9:25. doi: 10.1186/s13072-016-0074-4. X-127358653
5973 Posner DS. Review of Autism and understanding: The Waldon approach to child development. Journal of Autism and Developmental Disorders. 2016;46(4):1498–9. doi: http://dx.doi.org/10.1007/s10803-015-2658-4. X-1, X-2
5974 Posserud M, Hysing M, Helland W, . Autism traits: The importance of “co-morbid” problems for impairment and contact with services. Data from the Bergen Child Study. Res Dev Disabil. 2016 Jan 27 doi: 10.1016/j.ridd.2016.01.002. X-1
5975 Poustka L, Kamp-Becker I. Current Practice and Future Avenues in Autism Therapy. Curr Top Behav Neurosci. 2016 Apr 30 doi: 10.1007/7854_2016_442. X-1
5976 Powell G, Wass SV, Erichsen JT, . First evidence of the feasibility of gaze-contingent attention training for school children with autism. Autism. 2016 Feb 9 doi: 10.1177/1362361315617880. X-1
5977 Prager EM, Bergstrom HC, Wynn GH, . The basolateral amygdala gamma-aminobutyric acidergic system in health and disease. J Neurosci Res. 2016 Jun;94(6):548–67. doi: 10.1002/jnr.23690. X-126586374
5978 Preckel K, Kanske P, Singer T, . Clinical trial of modulatory effects of oxytocin treatment on higher-order social cognition in autism spectrum disorder: a randomized, placebo-controlled, double-blind and crossover trial. BMC Psychiatry. 2016;16(1):329. doi: 10.1186/s12888-016-1036-x. X-2, X-327655235
5979 Preis J, Amon R, Robinette DS, . Does music matter? The effects of background music on verbal expression and engagement in children with autism spectrum disorders. Music Therapy Perspectives. 2016;34(1):106–15. doi: http://dx.doi.org/10.1093/mtp/miu044. X-3, X-4
5980 Prince EB, Kim ES, Wall CA, . The relationship between autism symptoms and arousal level in toddlers with autism spectrum disorder, as measured by electrodermal activity. Autism. 2016 Jun 10 doi: 10.1177/1362361316648816. X-1
5981 Prins BP, Abbasi A, Wong A, . Investigating the Causal Relationship of C-Reactive Protein with 32 Complex Somatic and Psychiatric Outcomes: A Large-Scale Cross-Consortium Mendelian Randomization Study. PLoS Med. 2016 Jun;13(6):e1001976. doi: 10.1371/journal.pmed.1001976. X-127327646
5982 Pritchard MA, de Dassel T, Beller E, . Autism in Toddlers Born Very Preterm. Pediatrics. 2016 Feb;137(2):e20151949. doi: 10.1542/peds.2015-1949. X-126798043
5983 Pruett JR, Jr, Povinelli DJ. Commentary - Autism Spectrum Disorder: Spectrum or Cluster? Autism Res. 2016 Jun 22 doi: 10.1002/aur.1650. X-1, X-2
5984 Pruitt MM, Willis K, Timmons L, . The impact of maternal, child, and family characteristics on the daily well-being and parenting experiences of mothers of children with autism spectrum disorder. Autism. 2016 Feb 5 doi: 10.1177/1362361315620409. X-1
5985 Puente AE, Heller S, Sekely A. Neuropsychological Analysis of an Idiot Savant: A Case Study. Appl Neuropsychol Adult. 2016 May 9:1–5. doi: 10.1080/23279095.2016.1159563. X-1
5986 Puig-Alcaraz C, Fuentes-Albero M, Cauli O. Relationship between adipic acid concentration and the core symptoms of autism spectrum disorders. Psychiatry Res. 2016 May 25;242:39–45. doi: 10.1016/j.psychres.2016.05.027. X-127259135
5987 Pujals E, Batlle S, Camprodon E, . Brief report: Translation and adaptation of the Theory of Mind Inventory to Spanish. Journal of Autism and Developmental Disorders. 2016;46(2):685–90. doi: http://dx.doi.org/10.1007/s10803-015-2576-5. X-126373766
5988 Puka K, Smith ML, Moineddin R, . Health resource utilization varies by comorbidities in children with epilepsy. Epilepsy & Behavior. 2016;57(Part A):151–4. doi: http://dx.doi.org/10.1016/j.yebeh.2016.02.011. X-126953845
5989 Pusponegoro HD, Efar P, Soedjatmiko, . Gross Motor Profile and Its Association with Socialization Skills in Children with Autism Spectrum Disorders. Pediatr Neonatol. 2016 Apr 2 doi: 10.1016/j.pedneo.2016.02.004. X-1
5990 Putnam PT, Roman JM, Zimmerman PE, . Oxytocin enhances gaze-following responses to videos of natural social behavior in adult male rhesus monkeys. Psychoneuroendocrinology. 2016 Jun 3;72:47–53. doi: 10.1016/j.psyneuen.2016.05.016. X-127343726
5991 Puvanesarajah V, Shen FH, Cancienne JM, . Risk factors for revision surgery following primary adult spinal deformity surgery in patients 65 years and older. J Neurosurg Spine. 2016 May 6:1–8. doi: 10.3171/2016.2.spine151345. X-1
5992 Qin L, Dai X, Yin Y. Valproic acid exposure sequentially activates Wnt and mTOR pathways in rats. Mol Cell Neurosci. 2016 Jun 23;75:27–35. doi: 10.1016/j.mcn.2016.06.004. X-127343825
5993 Qiu T, Chang C, Li Y, . Two years changes in the development of caudate nucleus are involved in restricted repetitive behaviors in 2–5-year-old children with autism spectrum disorder. Developmental Cognitive Neuroscience. 2016;19:137–43. doi: http://dx.doi.org/10.1016/j.dcn.2016.02.010. X-126999477
5994 Quigley J, McNally S, Lawson S. Prosodic patterns in interaction of low-risk and at-risk-of-autism spectrum disorders infants and their mothers at 12 and 18 months. Language Learning and Development. 2016;12(3):295–310. doi: http://dx.doi.org/10.1080/15475441.2015.1075405. X-1
5995 Rademacher L, Schulte-Ruther M, Hanewald B, . Reward: From Basic Reinforcers to Anticipation of Social Cues. Curr Top Behav Neurosci. 2016 Jan 5 doi: 10.1007/7854_2015_429. X-1
5996 Radley KC, Dart EH, Moore JW, . Promoting Accurate Variability of Social Skills in Children With Autism Spectrum Disorder. Behav Modif. 2016 Jul 5 doi: 10.1177/0145445516655428. X-3, X-4
5997 Radley KC, Hanglein J, Arak M. School-based social skills training for preschool-age children with autism spectrum disorder. Autism. 2016 Feb 5 doi: 10.1177/1362361315617361. X-1, X-3, X-4
5998 Raffard S, Bortolon C, Khoramshahi M, . Humanoid robots versus humans: How is emotional valence of facial expressions recognized by individuals with schizophrenia? An exploratory study. Schizophr Res. 2016 Jun 9 doi: 10.1016/j.schres.2016.06.001. X-1
5999 Rafie F, Ghasemi A, Zamani Jam A, . Effect of exercise intervention on the perceptual- motor skills in adolescents with autism. J Sports Med Phys Fitness. 2016 Mar 30. X-1, X-3
6000 Rahimi-Golkhandan S, Steenbergen B, Piek JP, . Revealing hot executive function in children with motor coordination problems: What’s the go? Brain and Cognition. 2016;106:55–64. doi: http://dx.doi.org/10.1016/j.bandc.2016.04.010. X-127254817
6001 Rahman A, Divan G, Hamdani SU, . Effectiveness of the parent-mediated intervention for children with autism spectrum disorder in south Asia in India and Pakistan (PASS): a randomised controlled trial. Lancet Psychiatry. 2016 Feb;3(2):128–36. doi: 10.1016/s2215-0366(15)00388-0. X-126704571
6002 Rai V. Association of methylenetetrahydrofolate reductase (MTHFR) gene C677T polymorphism with autism: evidence of genetic susceptibility. Metab Brain Dis. 2016 Mar 8 doi: 10.1007/s11011-016-9815-0. X-1
6003 Ramaekers VT, Sequeira JM, Quadros EV. The basis for folinic acid treatment in neuro-psychiatric disorders. Biochimie. 2016 Jul;126:79–90. doi: 10.1016/j.biochi.2016.04.005. X-127068282
6004 Ramoglu MG, Ucar T, Tutar E. Early malfunction of polyvinyl alcohol membrane of septal occluder. Catheter Cardiovasc Interv. 2016 Mar;87(4):E151–e3. doi: 10.1002/ccd.26057. X-126106065
6005 Ranasinghe KG, Rankin KP, Pressman PS, . Distinct Subtypes of Behavioral Variant Frontotemporal Dementia Based on Patterns of Network Degeneration. JAMA Neurol. 2016 Jul 18 doi: 10.1001/jamaneurol.2016.2016. X-1
6006 Rangarajan P, Karthikeyan A, Dheen ST. Role of dietary phenols in mitigating microglia-mediated neuroinflammation. Neuromolecular Med. 2016 Jul 27 doi: 10.1007/s12017-016-8430-x. X-1
6007 Ranger P, Ellenbroek BA. Perinatal Influences of Valproate on Brain and Behaviour: An Animal Model for Autism. Curr Top Behav Neurosci. 2016;29:363–86. doi: 10.1007/7854_2015_404. X-126510739
6008 Rankin JA, Weber RJ, Kang E, . Parent- and self-reported social skills importance in autism spectrum disorder. Journal of Autism and Developmental Disorders. 2016;46(1):273–86. doi: http://dx.doi.org/10.1007/s10803-015-2574-7. X-126329638
6009 Rapp JT, Cook JL, McHugh C, . Decreasing Stereotypy Using NCR and DRO With Functionally Matched Stimulation: Effects on Targeted and Non-Targeted Stereotypy. Behav Modif. 2016 Jun 7 doi: 10.1177/0145445516652370. X-1
6010 Rapp JT, Gunby K. Task interspersal for individuals with autism and other neurodevelopmental disorders. J Appl Behav Anal. 2016 May 27 doi: 10.1002/jaba.319. X-1
6011 Rappaport SR, Kanter C, Anast K. Special considerations in child custody evaluations for children with high-functioning autism spectrum disorder. Family Court Review. 2016;54(1):81–95. doi: http://dx.doi.org/10.1111/fcre.12206. X-1
6012 Ratsep MT, Paolozza A, Hickman AF, . Brain Structural and Vascular Anatomy Is Altered in Offspring of Pre-Eclamptic Pregnancies: A Pilot Study. AJNR Am J Neuroradiol. 2016 May;37(5):939–45. doi: 10.3174/ajnr.A4640. X-126721772
6013 Ratto AB, Anthony BJ, Pugliese C, . Lessons learned: Engaging culturally diverse families in neurodevelopmental disorders intervention research. Autism. 2016 Jun 15 doi: 10.1177/1362361316650394. X-1, X-2
6014 Rauh VA, Margolis AE. Research review: Environmental exposures, neurodevelopment, and child mental health—New paradigms for the study of brain and behavioral effects. Journal of Child Psychology and Psychiatry. 2016;57(7):775–93. doi: http://dx.doi.org/10.1111/jcpp.12537. X-126987761
6015 Rausch A, Zhang W, Haak KV, . Altered functional connectivity of the amygdaloid input nuclei in adolescents and young adults with autism spectrum disorder: a resting state fMRI study. Mol Autism. 2016;7:13. doi: 10.1186/s13229-015-0060-x. X-126823966
6016 Rayan A, Ahmad M. Effectiveness of mindfulness-based interventions on quality of life and positive reappraisal coping among parents of children with autism spectrum disorder. Res Dev Disabil. 2016 Apr 20;55:185–96. doi: 10.1016/j.ridd.2016.04.002. X-127107368
6017 Raynal P, Melioli T, Chabrol H. Personality profiles in young adults with disordered eating behavior. Eat Behav. 2016 Jun 3;22:119–23. doi: 10.1016/j.eatbeh.2016.06.020. X-127289047
6018 Reddish P, Tok P, Kundt R. Religious cognition and behaviour in autism: The role of mentalizing. International Journal for the Psychology of Religion. 2016;26(2):95–112. doi: http://dx.doi.org/10.1080/10508619.2014.1003518. X-1
6019 Reed P, Sejunaite K, Osborne LA. Relationship between self-reported health and stress in mothers of children with autism spectrum disorders. Journal of Autism and Developmental Disorders. 2016;46(3):934–41. doi: http://dx.doi.org/10.1007/s10803-015-2638-8. X-126527109
6020 Reid DB. Hypnosis Without Empathy? Perspectives From Autistic Spectrum Disorder and Stage Hypnosis. Am J Clin Hypn. 2016 Jan;58(3):304–20. doi: 10.1080/00029157.2015.1103204. X-126675158
6021 Reiner G. Inborn error metabolic screening in nonsyndromic autism spectrum disorders. Dev Med Child Neurol. 2016 May 12 doi: 10.1111/dmcn.13150. X-1
6022 Reinvall O, Moisio A-L, Lahti-Nuuttila P, . Psychiatric symptoms in children and adolescents with higher functioning autism spectrum disorders on the Development and Well-Being Assessment. Research in Autism Spectrum Disorders. 2016;25:47–57. doi: http://dx.doi.org/10.1016/j.rasd.2016.01.009. X-1
6023 Rendall AR, Truong DT, Fitch RH. Learning delays in a mouse model of Autism Spectrum Disorder. Behav Brain Res. 2016 Apr 15;303:201–7. doi: 10.1016/j.bbr.2016.02.006. X-126873041
6024 Rengit AC, McKowen JW, O’Brien J, . Brief Report: Autism Spectrum Disorder and Substance Use Disorder: A Review and Case Study. J Autism Dev Disord. 2016 Jul;46(7):2514–9. doi: 10.1007/s10803-016-2763-z. X-126944591
6025 Retico A, Giuliano A, Tancredi R, . The effect of gender on the neuroanatomy of children with autism spectrum disorders: a support vector machine case-control study. Mol Autism. 2016;7:5. doi: 10.1186/s13229-015-0067-3. X-126788282
6026 Rice K, Redcay E. Interaction matters: A perceived social partner alters the neural processing of human speech. Neuroimage. 2016 Apr 1;129:480–8. doi: 10.1016/j.neuroimage.2015.11.041. X-126608245
6027 Richard AC, Rovelet-Lecrux A, Delaby E, . The 22q11 PRODH/DGCR6 deletion is frequent in hyperprolinemic subjects but is not a strong risk factor for ASD. American Journal of Medical Genetics Part B: Neuropsychiatric Genetics. 2016;171(3):377–82. doi: http://dx.doi.org/10.1002/ajmg.b.32416. X-1
6028 Richards C, Moss J, Nelson L, . Persistence of self-injurious behaviour in autism spectrum disorder over 3 years: A prospective cohort study of risk markers. Journal of Neurodevelopmental Disorders. 2016;8 doi: http://dx.doi.org/10.1186/s11689-016-9153-x. X-126981159
6029 Riddle K, Cascio CJ, Woodward ND. Brain structure in autism: a voxel-based morphometry analysis of the Autism Brain Imaging Database Exchange (ABIDE). Brain Imaging Behav. 2016 Mar 3 doi: 10.1007/s11682-016-9534-5. X-1
6030 Rigatelli G, Dell’Avvocata F, Giordan M, . Incomplete Cor Triatriatum Dexter and Its Clinical and Technical Implications in Interatrial Shunt Device-Based Closure: An Intracardiac Echocardiography Study. Congenit Heart Dis. 2016 Feb 17 doi: 10.1111/chd.12326. X-1
6031 Rigatelli G, Pedon L, Zecchel R, . Long-Term Outcomes and Complications of Intracardiac Echocardiography-Assisted Patent Foramen Ovale Closure in 1,000 Consecutive Patients. J Interv Cardiol. 2016 Aug 8 doi: 10.1111/joic.12325. X-1
6032 Rizzo R, Pavone P. Aripiprazole for the treatment of irritability and aggression in children and adolescents affected by autism spectrum disorders. Expert Rev Neurother. 2016 Aug;16(8):867–74. doi: 10.1080/14737175.2016.1211007. X-1, X-227388494
6033 Roane HS, Fisher WW, Carr JE. Applied Behavior Analysis as Treatment for Autism Spectrum Disorder. J Pediatr. 2016 May 11 doi: 10.1016/j.jpeds.2016.04.023. X-1, X-2
6034 Roberts JE, McCary LM, Shinkareva SV, . Infant development in fragile X syndrome: Cross-syndrome comparisons. Journal of Autism and Developmental Disorders. 2016;46(6):2088–99. doi: http://dx.doi.org/10.1007/s10803-016-2737-1. X-126864160
6035 Roberts RM, Ejova A, Giallo R, . Support group programme for siblings of children with special needs: predictors of improved emotional and behavioural functioning. Disabil Rehabil. 2016 Jan 5:1–10. doi: 10.3109/09638288.2015.1116621. X-1
6036 Robins DL, Adamson LB, Barton M, . Universal autism screening for toddlers: Recommendations at odds. Journal of Autism and Developmental Disorders. 2016;46(5):1880–2. doi: http://dx.doi.org/10.1007/s10803-016-2697-5. X-126820633
6037 Robinson AN, Roberts JE, Brady NC, . Physiological correlates of maternal responsivity in mothers of preschoolers with fragile X syndrome. American Journal on Intellectual and Developmental Disabilities. 2016;121(2):111–20. doi: http://dx.doi.org/10.1352/1944-7558-121.2.111. X-126914466
6038 Robinson KJ, Hurd PL, Read S, . The PCSK6 gene is associated with handedness, the autism spectrum, and magical ideation in a non-clinical population. Neuropsychologia. 2016 Apr;84:205–12. doi: 10.1016/j.neuropsychologia.2016.02.020. X-126921480
6039 Robinson S, Howlin P, Russell A. Personality traits, autobiographical memory and knowledge of self and others: A comparative study in young people with autism spectrum disorder. Autism. 2016 May 19 doi: 10.1177/1362361316645429. X-1
6040 Robinson-Shelton A, Malow BA. Sleep Disturbances in Neurodevelopmental Disorders. Curr Psychiatry Rep. 2016 Jan;18(1):6. doi: 10.1007/s11920-015-0638-1. X-126719309
6041 Rodenas-Cuadrado P, Pietrafusa N, Francavilla T, . Characterisation of CASPR2 deficiency disorder--a syndrome involving autism, epilepsy and language impairment. BMC Med Genet. 2016;17:8. doi: 10.1186/s12881-016-0272-8. X-126843181
6042 Rodgers J, Wigham S, McConachie H, . Development of the anxiety scale for children with autism spectrum disorder (ASC-ASD). Autism Res. 2016 Feb 17 doi: 10.1002/aur.1603. X-1
6043 Rodgers JD, Warhol A, Fox JD, . Minimal risk of internalizing problems in typically-developing siblings of children with high-functioning autism spectrum disorder. Journal of Child and Family Studies. 2016;25(8):2554–61. doi: http://dx.doi.org/10.1007/s10826-016-0407-8. X-1
6044 Rodogno R, Krause-Jensen K, Ashcroft RE. ‘Autism and the good life’: a new approach to the study of well-being. J Med Ethics. 2016 Jun;42(6):401–8. doi: 10.1136/medethics-2016-103595. X-127174806
6045 Rodríguez-Barranco M, Gil F, Hernández AF, . Postnatal arsenic exposure and attention impairment in school children. Cortex: A Journal Devoted to the Study of the Nervous System and Behavior. 2016;74:370–82. doi: http://dx.doi.org/10.1016/j.cortex.2014.12.018. X-125682472
6046 Romano E, Cosentino L, Laviola G, . Genes and sex hormones interaction in neurodevelopmental disorders. Neurosci Biobehav Rev. 2016 Mar 4 doi: 10.1016/j.neubiorev.2016.02.019. X-1
6047 Ronconi L, Casartelli L, Carna S, . When one is Enough: Impaired Multisensory Integration in Cerebellar Agenesis. Cereb Cortex. 2016 Mar 5 doi: 10.1093/cercor/bhw049. X-1
6048 Ronconi L, Franchin L, Valenza E, . The attentional ‘zoom-lens’ in 8-month-old infants. Developmental Science. 2016;19(1):145–54. doi: http://dx.doi.org/10.1111/desc.12288. X-125702701
6049 Rooney GE, Goodwin AF, Depeille P, . Human iPS Cell-Derived Neurons Uncover the Impact of Increased Ras Signaling in Costello Syndrome. J Neurosci. 2016 Jan 6;36(1):142–52. doi: 10.1523/jneurosci.1547-15.2016. X-126740656
6050 Rosa M, Puig O, Lazaro L, . Socioeconomic status and intelligence quotient as predictors of psychiatric disorders in children and adolescents with high-functioning autism spectrum disorder and in their siblings. Autism. 2016 Feb 5 doi: 10.1177/1362361315617881. X-1
6051 Rosch KS, Dirlikov B, Mostofsky SH. Corrigendum to “Reduced intrasubject variability with reinforcement in boys, but not girls, with ADHD: Associations with prefrontal anatomy” [Biol. Psychol. 110 (2015) 12–23]. Biol Psychol. 2016 May;117:239. doi: 10.1016/j.biopsycho.2016.01.004. X-127180014
6052 Rose V, Trembath D, Keen D, . The proportion of minimally verbal children with autism spectrum disorder in a community-based early intervention programme. Journal of Intellectual Disability Research. 2016;60(5):464–77. doi: http://dx.doi.org/10.1111/jir.12284. X-127120989
6053 Rosen TE, Lerner MD. Externalizing and Internalizing Symptoms Moderate Longitudinal Patterns of Facial Emotion Recognition in Autism Spectrum Disorder. J Autism Dev Disord. 2016 Apr 28 doi: 10.1007/s10803-016-2800-y. x-1
6054 Roskam I, Stievenart M, de Mol J. The transactional process between the relationships with caregivers and children’s externalizing behavior. Journal of Applied Developmental Psychology. 2016;42:31–9. doi: http://dx.doi.org/10.1016/j.appdev.2015.11.003. X-1
6055 Ruiz LM, Damron M, Jones KB, . Antipsychotic use and metabolic monitoring in individuals with developmental disabilities served in a Medicaid medical home. Journal of Autism and Developmental Disorders. 2016;46(6):1887–94. doi: http://dx.doi.org/10.1007/s10803-016-2712-x. X-126818535
6056 Rumondor AC, Dhareshwar SS, Kesisoglou F. Amorphous Solid Dispersions or Prodrugs: Complementary Strategies to Increase Drug Absorption. J Pharm Sci. 2016 Jan 22 doi: 10.1016/j.xphs.2015.11.004. X-1
6057 Ruparelia K, Abubakar A, Badoe E, . Autism Spectrum Disorders in Africa: Current Challenges in Identification, Assessment, and Treatment: A Report on the International Child Neurology Association Meeting on ASD in Africa, Ghana, April 3–5, 2014. J Child Neurol. 2016 Jul;31(8):1018–26. doi: 10.1177/0883073816635748. X-126979098
6058 Russell AE, Ford T, Williams R, . The association between socioeconomic disadvantage and attention deficit/hyperactivity disorder (ADHD): A systematic review. Child Psychiatry and Human Development. 2016;47(3):440–58. doi: http://dx.doi.org/10.1007/s10578-015-0578-3. X-126266467
6059 Russo-Ponsaran NM, Evans-Smith B, Johnson J, . Efficacy of a facial emotion training program for children and adolescents with autism spectrum disorders. Journal of Nonverbal Behavior. 2016;40(1):13–38. doi: http://dx.doi.org/10.1007/s10919-015-0217-5. X-1
6060 Rutherford M, McKenzie K, Johnson T, . Gender ratio in a clinical population sample, age of diagnosis and duration of assessment in children and adults with autism spectrum disorder. Autism. 2016;20(5):628–34. doi: http://dx.doi.org/10.1177/1362361315617879. X-126825959
6061 Rutherford M, McKenzie K, McClure I, . A national study to investigate the clinical use of standardised instruments in autism spectrum disorder assessment of children and adults in Scotland. Research in Autism Spectrum Disorders. 2016;29–30:93–100. doi: http://dx.doi.org/10.1016/j.rasd.2016.05.003. X-1
6062 Rutherford MD, Subiaul F. Children with autism spectrum disorder have an exceptional explanatory drive. Autism. 2016;20(6):744–53. doi: http://dx.doi.org/10.1177/1362361315605973. X-126503988
6063 Ruzich E, Allison C, Smith P, . The Autism-Spectrum Quotient in Siblings of People With Autism. Autism Res. 2016 Jun 22 doi: 10.1002/aur.1651. X-1
6064 Ruzzo EK, Geschwind DH. Schizophrenia genetics complements its mechanistic understanding. Nat Neurosci. 2016 Apr;19(4):523–5. doi: 10.1038/nn.4277. X-126998600
6065 Ryan C, Furley P, Mulhall K. Judgments of Nonverbal Behaviour by Children with High-Functioning Autism Spectrum Disorder: Can they Detect Signs of Winning and Losing from Brief Video Clips? J Autism Dev Disord. 2016 Jun 15 doi: 10.1007/s10803-016-2839-9. X-1
6066 Rynkiewicz A, Schuller B, Marchi E, . An investigation of the ‘female camouflage effect’ in autism using a computerized ADOS-2 and a test of sex/gender differences. Mol Autism. 2016;7:10. doi: 10.1186/s13229-016-0073-0. X-126798446
6067 Rzhepetskyy Y, Lazniewska J, Proft J, . A Cav3.2/Stac1 molecular complex controls T-type channel expression at the plasma membrane. Channels (Austin). 2016 May 5:1–9. doi: 10.1080/19336950.2016.1186318. X-1
6068 Saad AF, Alshehri W, Lei J, . Maternal Fructose Consumption Disrupts Brain Development of Offspring in a Murine Model of Autism Spectrum Disorder. Am J Perinatol. 2016 May 2 doi: 10.1055/s-0036-1583292. X-1
6069 Sabatos-DeVito M, Schipul SE, Bulluck JC, . Eye tracking reveals impaired attentional disengagement associated with sensory response patterns in children with autism. Journal of Autism and Developmental Disorders. 2016 2016-03-30;46(4):1319–33. doi: http://dx.doi.org/10.1007/s10803-015-2681-5; 2016-05140-001. X-126816345
6070 Saeedi Saravi SS, Dehpour AR. Potential role of organochlorine pesticides in the pathogenesis of neurodevelopmental, neurodegenerative, and neurobehavioral disorders: A review. Life Sci. 2016 Jan 15;145:255–64. doi: 10.1016/j.lfs.2015.11.006. X-1, X-226549647
6071 Sah SP, Bartakian S, El-Said H, . Preprocedural Transthoracic Echocardiography Can Predict Amplatzer Septal Occluder Device Size for Transcatheter Atrial Septal Defect Closure. Congenit Heart Dis. 2016 Apr 14 doi: 10.1111/chd.12365. X-1
6072 Saitovitch A, Popa T, Lemaitre H, . Tuning Eye-Gaze Perception by Transitory STS Inhibition. Cereb Cortex. 2016 Jun;26(6):2823–31. doi: 10.1093/cercor/bhw045. X-126946130
6073 Sajith SG, Liew SF, Tor PC. Response to Electroconvulsive Therapy in Patients With Autism Spectrum Disorder and Intractable Challenging Behaviors Associated With Symptoms of Catatonia. J ect.. 2016 Jul 16 doi: 10.1097/yct.0000000000000338. X-1
6074 Sakai K, Shoji H, Kohno T, . Mice that lack the C-terminal region of Reelin exhibit behavioral abnormalities related to neuropsychiatric disorders. Sci Rep. 2016;6:28636. doi: 10.1038/srep28636. X-127346785
6075 Sakaura H, Miwa T, Yamashita T, . Posterior lumbar interbody fusion with cortical bone trajectory screw fixation versus posterior lumbar interbody fusion using traditional pedicle screw fixation for degenerative lumbar spondylolisthesis: a comparative study. J Neurosurg Spine. 2016 May 27:1–5. doi: 10.3171/2016.3.spine151525. X-1
6076 Salatino-Oliveira A, Akutagava-Martins GC, Bruxel EM, . NOS1 and SNAP25 polymorphisms are associated with Attention-Deficit/Hyperactivity Disorder symptoms in adults but not in children. Journal of Psychiatric Research. 2016;75:75–81. doi: http://dx.doi.org/10.1016/j.jpsychires.2016.01.010. X-126821215
6077 Salatino-Oliveira A, Wagner F, Akutagava-Martins GC, . MAP1B and NOS1 genes are associated with working memory in youths with attention–deficit/hyperactivity disorder. European Archives of Psychiatry and Clinical Neuroscience. 2016;266(4):359–66. doi: http://dx.doi.org/10.1007/s00406-015-0626-9. X-126233433
6078 Salles J, Strelnikov K, Carine M, . Deficits in voice and multisensory processing in patients with Prader-Willi syndrome. Neuropsychologia. 2016 May;85:137–47. doi: 10.1016/j.neuropsychologia.2016.03.015. X-126994593
6079 Salomone E, Maurizio Arduino G. Parental attitudes to a telehealth parent coaching for autism spectrum disorder. J Telemed Telecare. 2016 Apr 6 doi: 10.1177/1357633x16642067. X-1, X-3
6080 Salter K, Beamish W, Davies M. The effects of child-centered play therapy (CCPT) on the social and emotional growth of young Australian children with autism. International Journal of Play Therapy. 2016;25(2):78–90. doi: http://dx.doi.org/10.1037/pla0000012. X-3, X-4
6081 Salvano-Pardieu V, Blanc R, Combalbert N, . Judgment of blame in teenagers with Asperger’s syndrome. Thinking & Reasoning. 2016;22(3):251–73. doi: http://dx.doi.org/10.1080/13546783.2015.1127288. X-1
6082 Samanta D. Severe developmental delay and complete agenesis of corpus callosum in a Noonan syndrome patient with SOS1 mutation. Acta Neurologica Belgica. 2016;116(2):223–4. doi: http://dx.doi.org/10.1007/s13760-015-0526-9. X-126280111
6083 Sanders EJ, Irvin DW, Belardi K, . The questions verbal children with autism spectrum disorder encounter in the inclusive preschool classroom. Autism. 2016;20(1):96–105. doi: http://dx.doi.org/10.1177/1362361315569744. X-125748026
6084 Sanefuji M, Craig M, Parlatini V, . Double-dissociation between the mechanism leading to impulsivity and inattention in Attention Deficit Hyperactivity Disorder: A resting-state functional connectivity study. Cortex. 2016 Jun 16 doi: 10.1016/j.cortex.2016.06.005. X-1
6085 Sanmann JN, Casas KA, Bevilacqua J, . The first patient with tandem duplication of 6q14q16: Molecular and phenotypic characterization. Am J Med Genet A. 2016 Jun 23 doi: 10.1002/ajmg.a.37797. X-1
6086 Santa Maria L, Aliaga S, Faundes V, . FMR1 gene mutations in patients with fragile X syndrome and obligate carriers: 30 years of experience in Chile. Genet Res (Camb). 2016;98:e11. doi: 10.1017/s0016672316000082. X-127350105
6087 Santarosa LMC, Conforto D. Educational and digital inclusion for subjects with autism spectrum disorders in 1:1 technological configuration. Computers in Human Behavior. 2016;60:293–300. doi: http://dx.doi.org/10.1016/j.chb.2016.02.021. X-1, X-3, X-4
6088 Santocchi E, Guiducci L, Fulceri F, . Gut to brain interaction in Autism Spectrum Disorders: a randomized controlled trial on the role of probiotics on clinical, biochemical and neurophysiological parameters. BMC Psychiatry. 2016;16:183. doi: 10.1186/s12888-016-0887-5. X-2, X-327260271
6089 Saresella M, Piancone F, Marventano I, . Multiple inflammasome complexes are activated in autistic spectrum disorders. Brain Behav Immun. 2016 Mar 12 doi: 10.1016/j.bbi.2016.03.009. X-1
6090 Sarnat H, Samuel E, Ashkenazi-Alfasi N, . Oral Health Characteristics of Preschool Children with Autistic Syndrome Disorder. J Clin Pediatr Dent. 2016 Winter;40(1):21–5. doi: 10.17796/1053-4628-40.1.21. X-126696102
6091 Sarowar T, Chhabra R, Vilella A, . Activity and circadian rhythm influence synaptic Shank3 protein levels in mice. J Neurochem. 2016 Jun 22 doi: 10.1111/jnc.13709. X-1
6092 Satoh M, Obara T, Nishigori H, . Prescription trends in children with pervasive developmental disorders (PDD): A claims data-based study in Japan. World J Pediatr. 2016 Jun 10 doi: 10.1007/s12519-016-0036-8. X-1
6093 Scahill L, Bearss K, Lecavalier L, . Effect of Parent Training on Adaptive Behavior in Children With Autism Spectrum Disorder and Disruptive Behavior: Results of a Randomized Trial. J Am Acad Child Adolesc Psychiatry. 2016 Jul;55(7):602–9.e3. doi: 10.1016/j.jaac.2016.05.001. X-127343887
6094 Scahill L, Jeon S, Boorin SJ, . Weight gain and metabolic consequences of risperidone in young children with autism spectrum disorder. Journal of the American Academy of Child & Adolescent Psychiatry. 2016;55(5):415–23. doi: http://dx.doi.org/10.1016/j.jaac.2016.02.016.27126856
6095 Scemama C, Magrino B, Gillet P, . Risk of adjacent-segment disease requiring surgery after short lumbar fusion: results of the French Spine Surgery Society Series. J Neurosurg Spine. 2016 Jul;25(1):46–51. doi: 10.3171/2015.11.spine15700. X-126967992
6096 Schall U. Is it time to move mismatch negativity into the clinic? Biol Psychol. 2016 Apr;116:41–6. doi: 10.1016/j.biopsycho.2015.09.001. X-126342995
6097 Schatz RB, Peterson RK, Bellini S. The use of video self-modeling to increase on-task behavior in children with high-functioning autism. Journal of Applied School Psychology. 2016;32(3):234–53. doi: http://dx.doi.org/10.1080/15377903.2016.1183542. X-3, X-4
6098 Schauder KB, Bennetto L. Toward an Interdisciplinary Understanding of Sensory Dysfunction in Autism Spectrum Disorder: An Integration of the Neural and Symptom Literatures. Front Neurosci. 2016;10:268. doi: 10.3389/fnins.2016.00268. X-127378838
6099 Scheckel C, Drapeau E, Frias MA, . Regulatory consequences of neuronal ELAV-like protein binding to coding and non-coding RNAs in human brain. Elife. 2016;5 doi: 10.7554/eLife.10421. X-1
6100 Scheer JK, Hostin R, Robinson C, . Operative Management of Adult Spinal Deformity Results in Significant Increases in QALYs Gained Compared to Non-operative Management: Analysis of 479 patients with Minimum 2-year Follow-up. Spine (Phila Pa 1976). 2016 Apr 11 doi: 10.1097/brs.0000000000001626. X-1
6101 Scheer JK, Osorio JA, Smith JS, . Development of Validated Computer Based Pre-operative Predictive Model for Proximal Junction Failure (PJF) or Clinically Significant PJK with 86% Accuracy Based on 510 ASD Patients with 2-year Follow-up. Spine (Phila Pa 1976). 2016 Apr 1 doi: 10.1097/brs.0000000000001598. X-1
6102 Scheer JK, Passias PG, Sorocean AM, . Association between preoperative cervical sagittal deformity and inferior outcomes at 2-year follow-up in patients with adult thoracolumbar deformity: analysis of 182 patients. J Neurosurg Spine. 2016 Jan;24(1):108–15. doi: 10.3171/2015.3.spine141098. X-126360147
6103 Schelinski S, Borowiak K, von Kriegstein K. Temporal voice areas exist in autism spectrum disorder but are dysfunctional for voice identity recognition. Soc Cogn Affect Neurosci. 2016 Jun 30 doi: 10.1093/scan/nsw089. X-1
6104 Scherr JF, Hahn LJ, Hooper SR, . HPA axis function predicts development of working memory in boys with FXS. Brain and Cognition. 2016;102:80–90. doi: http://dx.doi.org/10.1016/j.bandc.2015.12.002. X-126760450
6105 Schlebusch L, Samuels AE, Dada S. South African families raising children with autism spectrum disorders: Relationship between family routines, cognitive appraisal and family quality of life. Journal of Intellectual Disability Research. 2016;60(5):412–23. doi: http://dx.doi.org/10.1111/jir.12292. X-127120985
6106 Schneider A, Johnston C, Tassone F, . Broad autism spectrum and obsessive-compulsive symptoms in adults with the fragile X premutation. Clin Neuropsychol. 2016 Jun 29:1–15. doi: 10.1080/13854046.2016.1189536. X-1
6107 Schneider HE, Lam JC, Mahone EM. Sleep disturbance and neuropsychological function in young children with ADHD. Child Neuropsychology. 2016;22(4):493–506. doi: http://dx.doi.org/10.1080/09297049.2015.1018153. X-125765292
6108 Schneider M, de Vries PJ, Schonig K, . mTOR inhibitor reverses autistic-like social deficit behaviours in adult rats with both Tsc2 haploinsufficiency and developmental status epilepticus. Eur Arch Psychiatry Clin Neurosci. 2016 Jun 4 doi: 10.1007/s00406-016-0703-8. X-1
6109 Schoch H, Kreibich AS, Ferri SL, . Sociability Deficits and Altered Amygdala Circuits in Mice Lacking Pcdh10, an Autism Associated Gene. Biol Psychiatry. 2016 Jun 16 doi: 10.1016/j.biopsych.2016.06.008. X-1
6110 Schrantee A, Tamminga HG, Bouziane C, . Age-Dependent Effects of Methylphenidate on the Human Dopaminergic System in Young vs Adult Patients With Attention-Deficit/Hyperactivity Disorder: A Randomized Clinical Trial. JAMA Psychiatry. 2016 Aug 3 doi: 10.1001/jamapsychiatry.2016.1572. X-1
6111 Schrooten I, Scholte RH, Cillessen AH, . Participant Roles in Bullying Among Dutch Adolescents With Autism Spectrum Disorders. J Clin Child Adolesc Psychol. 2016 Mar 30:1–14. doi: 10.1080/15374416.2016.1138411. X-1
6112 Schuch JB, Müller D, Endres RG, . Psychomotor agitation and mood instability in patients with autism spectrum disorders: A possible effect of SLC6A4 gene? Research in Autism Spectrum Disorders. 2016;26:48–56. doi: http://dx.doi.org/10.1016/j.rasd.2016.03.001. X-1
6113 Schuetze M, Park MT, Cho IY, . Morphological Alterations in the Thalamus, Striatum, and Pallidum in Autism Spectrum Disorder. Neuropsychopharmacology. 2016 Jun 8 doi: 10.1038/npp.2016.64. X-1
6114 Schuh JM, Eigsti IM, Mirman D. Discourse comprehension in autism spectrum disorder: Effects of working memory load and common ground. Autism Res. 2016 Apr 19 doi: 10.1002/aur.1632. X-1
6115 Schulte-Ruther M, Otte E, Adiguzel K, . Intact mirror mechanisms for automatic facial emotions in children and adolescents with autism spectrum disorder. Autism Res. 2016 Jun 28 doi: 10.1002/aur.1654. X-1
6116 Schulze A, Bauman M, Tsai AC, . Prevalence of Creatine Deficiency Syndromes in Children With Nonsyndromic Autism. Pediatrics. 2016 Jan;137(1)doi: 10.1542/peds.2015-2672. X-1
6117 Schur RR, Draisma LW, Wijnen JP, . Brain GABA levels across psychiatric disorders: A systematic literature review and meta-analysis of 1 H-MRS studies. Hum Brain Mapp. 2016 May 4 doi: 10.1002/hbm.23244. X-1
6118 Schwartzberg ET, Silverman MJ. Effects of a music-based short story on short- and long-term reading comprehension of individuals with Autism Spectrum Disorder: A cluster randomized study. The Arts in Psychotherapy. 2016;48:54–61. doi: http://dx.doi.org/10.1016/j.aip.2016.01.001. X-1, X-4
6119 Schwartzer JJ, Onore CE, Rose D, . C57BL/6J bone marrow transplant increases sociability in BTBR T+ Itpr3tf/J mice. Brain Behav Immun. 2016 May 26 doi: 10.1016/j.bbi.2016.05.019. X-1
6120 Schweitzer J, James C, Jenkins W, . Acute Agitation and Self-Injury in a 5-Year Old with Autism. J Dev Behav Pediatr. 2016 Jun 28 doi: 10.1097/dbp.0000000000000324. X-1
6121 Schwichtenberg AJ, Hensle T, Honaker S, . Sibling sleep—What can it tell us about parental sleep reports in the context of autism? Clinical Practice in Pediatric Psychology. 2016;4(2):137–52. doi: http://dx.doi.org/10.1037/cpp0000143. X-127563509
6122 Sciberras E, Bisset M, Hazell P, . Health-related impairments in young children with ADHD: A community-based study. Child: Care, Health and Development. 2016;42(5):709–17. doi: http://dx.doi.org/10.1111/cch.12363. X-1
6123 Sciubba DM, Scheer JK, Yurter A, . Patients with spinal deformity over the age of 75: a retrospective analysis of operative versus non-operative management. Eur Spine J. 2016 Aug;25(8):2433–41. doi: 10.1007/s00586-015-3759-7. X-125657104
6124 Scott RC, Tuchman R. Epilepsy and autism spectrum disorders: Relatively related. Neurology. 2016 Jun 15 doi: 10.1212/wnl.0000000000002852. X-1
6125 Scroggins ML, Litchke LG, Liu T. Effects of multisensory yoga on behavior in a male child with Apert and Asperger syndrome. Int J Yoga. 2016 Jan–Jun;9(1):81–4. doi: 10.4103/0973-6131.171716. X-1, X-3, X-426865777
6126 Sedgewick F, Hill V, Yates R, . Gender differences in the social motivation and friendship experiences of autistic and non-autistic adolescents. Journal of Autism and Developmental Disorders. 2016;46(4):1297–306. doi: http://dx.doi.org/10.1007/s10803-015-2669-1. X-126695137
6127 Sedney CL, Daffner SD, Stefanko JJ, . Fracture of fusion mass after hardware removal in patients with high sagittal imbalance. J Neurosurg Spine. 2016 Apr;24(4):639–43. doi: 10.3171/2015.7.spine15153. X-126682604
6128 Self TL, Parham DF. Students’ self-perceptions of interprofessional education following participation on a diagnostic team for autism spectrum disorder. J Interprof Care. 2016 Jun 17:1–3. doi: 10.1080/13561820.2016.1181615. X-1
6129 Sellers TP, Kelley K, Higbee TS, . Effects of simultaneous script training on use of varied mand frames by preschoolers with autism. Analysis of Verbal Behavior. 2016;32(1):15–26. doi: http://dx.doi.org/10.1007/s40616-015-0049-8. X-1, X-3, X-427606217
6130 Sellinger VJ, Elder JH. Parent Training Intervention to Manage Externalizing Behaviors in Children With Autism. J Pediatr Health Care. 2016 Jan–Feb;30(1):73–7. doi: 10.1016/j.pedhc.2015.10.002. X-3, X-426559136
6131 Semrud-Clikeman M, Fine JG, Bledsoe J. Social functioning using direct and indirect measures with children with High Functioning Autism, nonverbal learning disability, and typically developing children. Child Neuropsychol. 2016;22(3):318–35. doi: 10.1080/09297049.2014.994487. X-125711370
6132 Sener EF, Canatan H, Ozkul Y. Recent Advances in Autism Spectrum Disorders: Applications of Whole Exome Sequencing Technology. Psychiatry Investig. 2016 May;13(3):255–64. doi: 10.4306/pi.2016.13.3.255. X-1
6133 Sener EF, Uytun MC, Bayramov KK, . The roles of CC2D1A and HTR1A gene expressions in autism spectrum disorders. Metabolic Brain Disease. 2016;31(3):613–9. doi: http://dx.doi.org/10.1007/s11011-016-9795-0. X-126782176
6134 Senland AK, Higgins-D’Alessandro A. Sociomoral Reasoning, Empathy, and Meeting Developmental Tasks During the Transition to Adulthood in Autism Spectrum Disorder. J Autism Dev Disord. 2016 Jul 1 doi: 10.1007/s10803-016-2849-7. X-1
6135 Senokossoff GW. Developing reading comprehension skills in high-functioning children with autism spectrum disorder: A review of the research, 1990–2012. Reading & Writing Quarterly: Overcoming Learning Difficulties. 2016;32(3):223–46. doi: http://dx.doi.org/10.1080/10573569.2014.936574. X-1, X-2
6136 Sequeira JM, Desai A, Berrocal-Zaragoza MI, . Exposure to Folate Receptor Alpha Antibodies during Gestation and Weaning Leads to Severe Behavioral Deficits in Rats: A Pilot Study. PLoS One. 2016;11(3):e0152249. doi: 10.1371/journal.pone.0152249. X-127011008
6137 Shah P. Interoception: The Eighth Sensory System: Practical Solutions for Improving Self-Regulation, Self-Awareness and Social Understanding of Individuals with Autism Spectrum and Related Disorders : K. J. Mahler: Shawnee Mission KS, AAPC, 2015, 186 pp, $29.95 (paper), ISBN 978-1-942197-14-0. J Autism Dev Disord. 2016 Jun 25 doi: 10.1007/s10803-016-2848-8. X-1
6138 Shah P, Hall R, Catmur C, . Alexithymia, not autism, is associated with impaired interoception. Cortex. 2016 Apr 5;81:215–20. doi: 10.1016/j.cortex.2016.03.021. X-127253723
6139 Shamblin S, Graham D, Bianco JA. Creating trauma-informed schools for rural appalachia: The partnerships program for enhancing resiliency, confidence and workforce development in early childhood education. School Mental Health. 2016;8(1):189–200. doi: http://dx.doi.org/10.1007/s12310-016-9181-4. X-1
6140 Shang L, Henderson LB, Cho MT, . De novo missense variants in PPP2R5D are associated with intellectual disability, macrocephaly, hypotonia, and autism. Neurogenetics. 2016;17(1):43–9. doi: http://dx.doi.org/10.1007/s10048-015-0466-9. X-126576547
6141 Shapiro E, King K, Ahmed A, . The Neurobehavioral Phenotype in Mucopolysaccharidosis Type IIIB: an Exploratory Study. Mol Genet Metab Rep. 2016 Mar 1;6:41–7. doi: 10.1016/j.ymgmr.2016.01.003. X-126918231
6142 Sharda M, Foster NE, Tryfon A, . Language Ability Predicts Cortical Structure and Covariance in Boys with Autism Spectrum Disorder. Cereb Cortex. 2016 Feb 17 doi: 10.1093/cercor/bhw024. X-1
6143 Sharpe K, Di Pietro N, Jacob KJ, . A Dichotomy of Information-Seeking and Information-Trusting: Stem Cell Interventions and Children with Neurodevelopmental Disorders. Stem Cell Rev. 2016 Aug;12(4):438–47. doi: 10.1007/s12015-016-9667-3. X-127286955
6144 Sharpley CF, Bitsika V, Andronicos NM, . Is afternoon cortisol more reliable than waking cortisol in association studies of children with an ASD? Physiology & Behavior. 2016;155:218–23. doi: http://dx.doi.org/10.1016/j.physbeh.2015.12.020. X-126717863
6145 Sharpley CF, Bitsika V, Jesulola E, . The association between aspects of psychological resilience and subtypes of depression: implications for focussed clinical treatment models. Int J Psychiatry Clin Pract. 2016 Sep;20(3):151–6. doi: 10.1080/13651501.2016.1199810. X-127332989
6146 Sharpley CF, Christie DR, Bitsika V, . Trajectories of total depression and depressive symptoms in prostate cancer patients receiving six months of hormone therapy. Psychooncology. 2016 Feb 9 doi: 10.1002/pon.4100. X-1
6147 Shatrov AB, Soldatenko EV. Dermal glands in freshwater mites Limnesia undulata (O.F. Muller, 1776) and Limnesia fulgida (C.L. Koch, 1836) (Acariformes, Limnesiidae). Arthropod Struct Dev. 2016 Jun 14 doi: 10.1016/j.asd.2016.05.003. X-1
6148 Shehata AI, Hassanein FI, Abdul-Ghani R. Seroprevalence of Toxoplasma gondii infection among patients with non-schizophrenic neurodevelopmental disorders in Alexandria, Egypt. Acta Trop. 2016 Feb;154:155–9. doi: 10.1016/j.actatropica.2015.11.016. X-126656562
6149 Shelton AL, Cornish KM, Kraan CM, . Executive Dysfunction in Female FMR1 Premutation Carriers. Cerebellum. 2016 Apr 28 doi: 10.1007/s12311-016-0782-0. X-1
6150 Shen Q, Wang G, Li S, . ASD v3.0: unraveling allosteric regulation with structural mechanisms and biological networks. Nucleic Acids Res. 2016 Jan 4;44(D1):D527–35. doi: 10.1093/nar/gkv902. X-126365237
6151 Shen Y, Xun G, Guo H, . Association and gene–gene interactions study of reelin signaling pathway related genes with autism in the Han Chinese population. Autism Research. 2016;9(4):436–42. doi: http://dx.doi.org/10.1002/aur.1540. X-126285919
6152 Shermer M. The Quack of the Gaps Problem. Sci Am. 2016 Aug;315(2):75. doi: 10.1038/scientificamerican0816-75. X-1
6153 Shield A, Pyers J, Martin A, . Relations between language and cognition in native-signing children with autism spectrum disorder. Autism Res. 2016 Mar 3 doi: 10.1002/aur.1621. X-1
6154 Shillingsburg MA, Gayman CM, Walton W. Using textual prompts to teach mands for information using “who?”. Analysis of Verbal Behavior. 2016;32(1):1–14. doi: http://dx.doi.org/10.1007/s40616-016-0053-7. X-1, X-3, X-427606218
6155 Shire SY, Gulsrud A, Kasari C. Increasing responsive parent–child interactions and joint engagement: Comparing the influence of parent-mediated intervention and parent psychoeducation. Journal of Autism and Developmental Disorders. 2016;46(5):1737–47. doi: http://dx.doi.org/10.1007/s10803-016-2702-z. X-126797940
6156 Shireman ML, Lerman DC, Hillman CB. Teaching social play skills to adults and children with autism as an approach to building rapport. J Appl Behav Anal. 2016 Mar 15 doi: 10.1002/jaba.299. X-1
6157 Shirley MD, Frelin L, López JS, . Copy number variants associated with 14 cases of self-injurious behavior. PLoS ONE. 2016;11(3). X-1
6158 Shochet IM, Saggers BR, Carrington SB, . The Cooperative Research Centre for Living with Autism (Autism CRC) Conceptual Model to Promote Mental Health for Adolescents with ASD. Clin Child Fam Psychol Rev. 2016 Jun;19(2):94–116. doi: 10.1007/s10567-016-0203-4. X-127072681
6159 Shrader-Frechette K, ChoGlueck C. Pesticides, Neurodevelopmental Disagreement, and Bradford Hill’s Guidelines. Account Res. 2016 Jun 27 doi: 10.1080/08989621.2016.1203786. X-1
6160 Shtayermman O. Review of CBT for children and adolescents with high functioning autism spectrum disorders. Journal of Autism and Developmental Disorders. 2016;46(4):1500–1. doi: http://dx.doi.org/10.1007/s10803-015-2686-0. X-1, X-2
6161 Silbaugh BC, Falcomata TS. Translational evaluation of a lag schedule and variability in food consumed by a boy with autism and food selectivity. Dev Neurorehabil. 2016 Mar 28:1–4. doi: 10.3109/17518423.2016.1146364. X-1, X-3
6162 Silva G, Ribeiro MJ, Costa GN, . Peripheral Attentional Targets under Covert Attention Lead to Paradoxically Enhanced Alpha Desynchronization in Neurofibromatosis Type 1. PLoS One. 2016;11(2):e0148600. doi: 10.1371/journal.pone.0148600. X-126881921
6163 Silva-Martinez GA, Rodriguez-Rios D, Alvarado-Caudillo Y, . Arachidonic and oleic acid exert distinct effects on the DNA methylome. Epigenetics. 2016 May 3;11(5):321–34. doi: 10.1080/15592294.2016.1161873. X-127088456
6164 Silverstein M, Radesky J. Embrace the Complexity: The US Preventive Services Task Force Recommendation on Screening for Autism Spectrum Disorder. Jama. 2016 Feb 16;315(7):661–2. doi: 10.1001/jama.2016.0051. X-126881368
6165 Simon DM, Wallace MT. Dysfunction of sensory oscillations in Autism Spectrum Disorder. Neurosci Biobehav Rev. 2016 Jul 19;68:848–61. doi: 10.1016/j.neubiorev.2016.07.016. X-127451342
6166 Simoni ZR. Do social skills mediate the relationship between ADHD and depression? Sociological Spectrum. 2016;36(2):109–22. doi: http://dx.doi.org/10.1080/02732173.2015.1095662. X-1
6167 Simonstein F, Mashiach-Eizenberg M. Attitudes Toward Autism Spectrum Disorders Among Students of Allied Health Professions. J Genet Couns. 2016 Jun 2 doi: 10.1007/s10897-016-9969-2. X-1
6168 Simsek S, Cetin I, Cim A, . Elevated levels of tissue plasminogen activator and E-selectin in male children with autism spectrum disorder. Autism Res. 2016 May 19 doi: 10.1002/aur.1638. X-1
6169 Sinclair D, Oranje B, Razak KA, . Sensory processing in autism spectrum disorders and Fragile X syndrome-From the clinic to animal models. Neurosci Biobehav Rev. 2016 May 24 doi: 10.1016/j.neubiorev.2016.05.029. X-1
6170 Singh JS. Parenting work and autism trajectories of care. Sociol Health Illn. 2016 Apr 25 doi: 10.1111/1467-9566.12437. X-1
6171 Singh NN, Lancioni GE, Karazsia BT, . Effects of Samatha meditation on active academic engagement and math performance of students with attention deficit/hyperactivity disorder. Mindfulness. 2016;7(1):68–75. doi: http://dx.doi.org/10.1007/s12671-015-0424-5. X-1
6172 Singh SK, Stogsdill JA, Pulimood NS, . Astrocytes Assemble Thalamocortical Synapses by Bridging NRX1alpha and NL1 via Hevin. Cell. 2016 Jan 14;164(1–2):183–96. doi: 10.1016/j.cell.2015.11.034. X-126771491
6173 Singman EL, Daphalapurkar N, White H, . Indirect traumatic optic neuropathy. Mil Med Res. 2016;3:2. doi: 10.1186/s40779-016-0069-2. X-126759722
6174 Sirin N, Tekin-Iftar E. Opinions of Turkish Parents and Teachers About Safety Skills Instruction to Children with Autism Spectrum Disorders: A Preliminary Investigation. J Autism Dev Disord. 2016 May 11 doi: 10.1007/s10803-016-2809-2. X-1
6175 Siu AL, Bibbins-Domingo K, Grossman DC, . Screening for Autism Spectrum Disorder in Young Children: US Preventive Services Task Force Recommendation Statement. Jama. 2016 Feb 16;315(7):691–6. doi: 10.1001/jama.2016.0018. X-126881372
6176 Siu W-K, Lam C-W, Gao W-W, . Unmasking a novel disease gene NEO1 associated with autism spectrum disorders by a hemizygous deletion on chromosome 15 and a functional polymorphism. Behavioural Brain Research. 2016;300:135–42. doi: http://dx.doi.org/10.1016/j.bbr.2015.10.041. X-126518331
6177 Sivarao DV, Chen P, Senapati A, . 40 Hz Auditory Steady-State Response Is a Pharmacodynamic Biomarker for Cortical NMDA Receptors. Neuropsychopharmacology. 2016 Feb 3 doi: 10.1038/npp.2016.17. X-1
6178 Skewes JC, Gebauer L. Brief Report: Suboptimal Auditory Localization in Autism Spectrum Disorder: Support for the Bayesian Account of Sensory Symptoms. J Autism Dev Disord. 2016 Jul;46(7):2539–47. doi: 10.1007/s10803-016-2774-9. X-127011323
6179 Skold A, Janeslatt GK. Self-rating of daily time management in children: psychometric properties of the Time-S. Scand J Occup Ther. 2016 Jul 8:1–9. doi: 10.1080/11038128.2016.1185465. X-1
6180 Skonieczna-Zydecka K, Gorzkowska I, Pierzak-Sominka J, . The Prevalence of Autism Spectrum Disorders in West Pomeranian and Pomeranian Regions of Poland. J Appl Res Intellect Disabil. 2016 Jan 14 doi: 10.1111/jar.12238. X-1
6181 Skosnik PD, Cortes-Briones JA. Targeting the ecology within: The role of the gut-brain axis and human microbiota in drug addiction. Med Hypotheses. 2016 Aug;93:77–80. doi: 10.1016/j.mehy.2016.05.021. X-127372861
6182 Slappendel G, Mandy W, van der Ende J, . Utility of the 3Di short version for the diagnostic assessment of autism spectrum disorder and compatibility with DSM-5. Journal of Autism and Developmental Disorders. 2016;46(5):1834–46. doi: http://dx.doi.org/10.1007/s10803-016-2713-9. X-126825661
6183 Slattery L, Crosland K, Iovannone R. An evaluation of a self-management intervention to increase on-task behavior with individuals diagnosed with attention-deficit/hyperactivity disorder. Journal of Positive Behavior Interventions. 2016;18(3):168–79. doi: http://dx.doi.org/10.1177/1098300715588282. X-1
6184 Smallwood M, Sareen A, Baker E, . Increased Risk of Autism Development in Children Whose Mothers Experienced Birth Complications or Received Labor and Delivery Drugs. ASN Neuro. 2016 Aug;8(4)doi: 10.1177/1759091416659742. X-1
6185 Smith CE, Carr EG, Moskowitz LJ. Fatigue as a biological setting event for severe problem behavior in autism spectrum disorder. Research in Autism Spectrum Disorders. 2016;23:131–44. doi: http://dx.doi.org/10.1016/j.rasd.2015.12.003. X-1, X-3, X-4
6186 Smith CJ, Rozga A, Matthews N, . Investigating the Accuracy of a Novel Telehealth Diagnostic Approach for Autism Spectrum Disorder. Psychol Assess. 2016 May 19 doi: 10.1037/pas0000317. X-1
6187 Smith DP, Eikeseth S, Fletcher SE, . Emergent intraverbal forms may occur as a result of listener training for children with autism. Analysis of Verbal Behavior. 2016;32(1):27–37. doi: http://dx.doi.org/10.1007/s40616-016-0057-3. X-1, X-427606219
6188 Smith E, Meyer BJ, Koerting J, . Preschool hyperactivity specifically elevates long-term mental health risks more strongly in males than females: a prospective longitudinal study through to young adulthood. Eur Child Adolesc Psychiatry. 2016 Jun 13 doi: 10.1007/s00787-016-0876-8. X-1
6189 Smith E, Thurm A, Greenstein D, . Cortical thickness change in autism during early childhood. Human Brain Mapping. 2016;37(7):2616–29. doi: http://dx.doi.org/10.1002/hbm.23195. X-127061356
6190 Smith IM. Expanding our understanding of behavioural difficulties associated with autism spectrum disorder. Dev Med Child Neurol. 2016 Feb;58(2):121–2. doi: 10.1111/dmcn.12855. X-126219422
6191 Smith J, Rho JM, Teskey GC. Ketogenic diet restores aberrant cortical motor maps and excitation-to-inhibition imbalance in the BTBR mouse model of autism spectrum disorder. Behav Brain Res. 2016 May 1;304:67–70. doi: 10.1016/j.bbr.2016.02.015. X-126876011
6192 Smith JC. The embodied becoming of autism and childhood: A storytelling methodology. Disability & Society. 2016;31(2):180–91. X-1
6193 Smith JS, Klineberg E, Lafage V, . Prospective multicenter assessment of perioperative and minimum 2-year postoperative complication rates associated with adult spinal deformity surgery. J Neurosurg Spine. 2016 Jul;25(1):1–14. doi: 10.3171/2015.11.spine151036. X-126918574
6194 Smith JS, Lafage V, Shaffrey CI, . Outcomes of Operative and Nonoperative Treatment for Adult Spinal Deformity: A Prospective, Multicenter, Propensity-Matched Cohort Assessment With Minimum 2-Year Follow-up. Neurosurgery. 2016 Jun;78(6):851–61. doi: 10.1227/neu.0000000000001116. X-126579966
6195 Smith L, Malcolm-Smith S, de Vries PJ. Translation and cultural appropriateness of the Autism Diagnostic Observation Schedule-2 in Afrikaans. Autism. 2016 May 25 doi: 10.1177/1362361316648469. X-1
6196 Smith LE, Hong J, Greenberg JS, . Change in the behavioral phenotype of adolescents and adults with FXS: Role of the family environment. Journal of Autism and Developmental Disorders. 2016;46(5):1824–33. doi: http://dx.doi.org/10.1007/s10803-016-2714-8. X-126861717
6197 Smith T, Aman MG, Arnold LE, . Atomoxetine and Parent Training for Children With Autism and Attention-Deficit/Hyperactivity Disorder: A 24-Week Extension Study. J Am Acad Child Adolesc Psychiatry. 2016 Oct;55(10):868–76.e2. doi: 10.1016/j.jaac.2016.06.015.27663942
6198 Smithers-Sheedy H, McIntyre S, Gibson C, . A special supplement: Findings from the australian cerebral palsy register, birth years 1993 to 2006. Developmental Medicine & Child Neurology. 2016;58(Suppl 2):5–10. doi: http://dx.doi.org/10.1111/dmcn.13026. X-1
6199 Smolensky MH, Hermida RC, Reinberg A, . Circadian disruption: New clinical perspective of disease pathology and basis for chronotherapeutic intervention. Chronobiol Int. 2016 Jun 16:1–19. doi: 10.1080/07420528.2016.1184678. X-1
6200 Snow M, Donnelly J. Factors Mediating Dysphoric Moods and Help Seeking Behaviour Among Australian Parents of Children with Autism. J Autism Dev Disord. 2016 Jun;46(6):1941–52. doi: 10.1007/s10803-016-2725-5. X-126858033
6201 So W-C, Wong MK-Y. I use my space not yours: Use of gesture space for referential identification among children with autism spectrum disorders. Research in Autism Spectrum Disorders. 2016;26:33–47. doi: http://dx.doi.org/10.1016/j.rasd.2016.03.005. X-1
6202 Söderlund GBW, Jobs EN. Differences in speech recognition between children with attention deficits and typically developed children disappear when exposed to 65 dB of auditory noise. Frontiers in Psychology. 2016;7. X-1
6203 Sokhadze EM, Tasman A, Sokhadze GE, . Behavioral, cognitive, and motor preparation deficits in a visual cued spatial attention task in autism spectrum disorder. Applied Psychophysiology and Biofeedback. 2016;41(1):81–92. doi: http://dx.doi.org/10.1007/s10484-015-9313-x. X-126377686
6204 Sollis E, Graham SA, Vino A, . Identification and functional characterization of de novo FOXP1 variants provides novel insights into the etiology of neurodevelopmental disorder. Hum Mol Genet. 2016 Feb 1;25(3):546–57. doi: 10.1093/hmg/ddv495. X-126647308
6205 Solomon M, McCauley JB, Iosif AM, . Cognitive control and episodic memory in adolescents with autism spectrum disorders. Neuropsychologia. 2016 May 13;89:31–41. doi: 10.1016/j.neuropsychologia.2016.05.013. X-127184119
6206 Solomon O, Heritage J, Yin L, . ‘What brings him here today?’: Medical problem presentation involving children with autism spectrum disorders and typically developing children. Journal of Autism and Developmental Disorders. 2016;46(2):378–93. doi: http://dx.doi.org/10.1007/s10803-015-2550-2. X-126463739
6207 Solso S, Xu R, Proudfoot J, . Diffusion tensor imaging provides evidence of possible axonal overconnectivity in frontal lobes in autism spectrum disorder toddlers. Biological Psychiatry. 2016;79(8):676–84. doi: http://dx.doi.org/10.1016/j.biopsych.2015.06.029.x-1 26300272
6208 Somogyi E, Kapitány E, Kenyeres K, . Visual feedback increases postural stability in children with autism spectrum disorder. Research in Autism Spectrum Disorders. 2016;29–30:48–56. doi: http://dx.doi.org/10.1016/j.rasd.2016.06.001. X-1
6209 Song Y, Hakoda Y, Sang B. A selective impairment in extracting fearful information from another’s eyes in Autism. Autism Res. 2016 Jan 18 doi: 10.1002/aur.1583. X-1
6210 Soroceanu A, Burton DC, Oren JH, . Medical Complications after Adult Spinal Deformity Surgery: Incidence, Risk factors, and Clinical Impact. Spine (Phila Pa 1976). 2016 Apr 19 doi: 10.1097/brs.0000000000001636. X-1
6211 Soumiya H, Godai A, Araiso H, . Neonatal Whisker Trimming Impairs Fear/Anxiety-Related Emotional Systems of the Amygdala and Social Behaviors in Adult Mice. PLoS One. 2016;11(6):e0158583. doi: 10.1371/journal.pone.0158583. X-127362655
6212 Sparapani N, Morgan L, Reinhardt VP, . Evaluation of classroom active engagement in elementary students with autism spectrum disorder. Journal of Autism and Developmental Disorders. 2016;46(3):782–96. doi: http://dx.doi.org/10.1007/s10803-015-2615-2. X-126433878
6213 Spaulding CJ, Lerner MD, Gadow KD. Trajectories and correlates of special education supports for youth with autism spectrum disorder and psychiatric comparisons. Autism. 2016 May 12 doi: 10.1177/1362361316645428. X-1
6214 Specht MW, Mahone EM, Kline T, . Efficacy of parent-delivered behavioral therapy for primary complex motor stereotypies. Dev Med Child Neurol. 2016 Jun 4 doi: 10.1111/dmcn.13164. X-1
6215 Spjut Jansson B, Miniscalco C, Westerlund J, . Children who screen positive for autism at 2.5 years and receive early intervention: a prospective naturalistic 2-year outcome study. Neuropsychiatr Dis Treat. 2016;12:2255–63. doi: 10.2147/ndt.s108899. X-127621636
6216 Sprafkin J, Steinberg EA, Gadow KD, . Agreement among categorical, dimensional, and impairment criteria for ADHD and common comorbidities. Journal of Attention Disorders. 2016;20(8):665–73. doi: http://dx.doi.org/10.1177/1087054712475083. X-123400215
6217 Spriggs AD, Gast DL, Knight VF. Video Modeling and Observational Learning to Teach Gaming Access to Students with ASD. J Autism Dev Disord. 2016 Jun 6 doi: 10.1007/s10803-016-2824-3. X-1
6218 Squeglia LM, Brammer WA, Ray LA, . Attention deficit/hyperactivity disorder (ADHD) symptoms predict alcohol expectancy development. Journal of Child & Adolescent Substance Abuse. 2016;25(2):169–79. doi: http://dx.doi.org/10.1080/1067828X.2014.969856. X-1
6219 Srinath S, Jacob P. Challenges in parent-mediated training in autism spectrum disorder. Lancet Psychiatry. 2016 Feb;3(2):93–5. doi: 10.1016/s2215-0366(15)00453-8. X-1, X-2, X-3, X-426704572
6220 Srinivasan SM, Bhat AN. Differences in object sharing between infants at risk for autism and typically developing infants from 9 to 15 months of age. Infant Behavior & Development. 2016;42:128–41. doi: http://dx.doi.org/10.1016/j.infbeh.2015.12.003. X-126803417
6221 Stace LB. Welcoming max: Increasing pediatric provider knowledge of service dogs. Complement Ther Clin Pract. 2016 Aug;24:57–66. doi: 10.1016/j.ctcp.2016.05.005. X-127502802
6222 Stadnick N, Chlebowski C, Baker-Ericzen M, . Psychiatric comorbidity in autism spectrum disorder: Correspondence between mental health clinician report and structured parent interview. Autism. 2016 Jul 11 doi: 10.1177/1362361316654083. X-1
6223 Stahmer AC, Brookman-Frazee L, Rieth SR, . Parent perceptions of an adapted evidence-based practice for toddlers with autism in a community setting. Autism. 2016 Apr 27 doi: 10.1177/1362361316637580. X-1
6224 Starck M, Grünwald J, Schlarb AA. Occurrence of ADHD in parents of ADHD children in a clinical sample. Neuropsychiatric Disease and Treatment. 2016;12. X-1
6225 Steel C. The Asperger’s defence in digital child pornography investigations. Psychiatry, Psychology and Law. 2016;23(3):473–82. doi: http://dx.doi.org/10.1080/13218719.2015.1080150. X-1
6226 Stefanelli G, Gandaglia A, Costa M, . Brain phosphorylation of MeCP2 at serine 164 is developmentally regulated and globally alters its chromatin association. Sci Rep. 2016;6:28295. doi: 10.1038/srep28295. X-127323888
6227 Steinbach JM, Garza ET, Ryan BC. Novel Object Exploration as a Potential Assay for Higher Order Repetitive Behaviors in Mice. J Vis Exp. 2016(114)doi: 10.3791/54324. X-1
6228 Steinfeld H, Cho MT, Retterer K, . Mutations in HIVEP2 are associated with developmental delay, intellectual disability, and dysmorphic features. Neurogenetics. 2016;17(3):159–64. doi: http://dx.doi.org/10.1007/s10048-016-0479-z. X-127003583
6229 Stephens RL, Sabatos-DeVito M, Reznick JS. The Development and Validation of Attention Constructs From the First Year Inventory. Psychol Assess. 2016 Aug 8 doi: 10.1037/pas0000380. X-1
6230 Stephenson J. Using the Choiceboard Creator™ app on an iPad© to teach choice making to a student with severe disabilities. AAC: Augmentative and Alternative Communication. 2016;32(1):49–57. doi: http://dx.doi.org/10.3109/07434618.2015.1136688. X-1, X-3, X-426837188
6231 Stephenson KG, Quintin EM, South M. Erratum to: Age-Related Differences in Response to Music-Evoked Emotion Among Children and Adolescents with Autism Spectrum Disorders. J Autism Dev Disord. 2016 Apr;46(4):1152. doi: 10.1007/s10803-015-2676-2. X-126701672
6232 Stephenson KG, Quintin EM, South M. Age-related differences in response to music-evoked emotion among children and adolescents with autism spectrum disorders. Journal of Autism and Developmental Disorders. 2016;46(4):1142–51. doi: http://dx.doi.org/10.1007/s10803-015-2624-1. X-1, X-326520146
6233 Sterponi L, de Kirby K. A Multidimensional Reappraisal of Language in Autism: Insights from a Discourse Analytic Study. J Autism Dev Disord. 2016 Feb;46(2):394–405. doi: 10.1007/s10803-015-2679-z. X-126701673
6234 Stessman HA, Willemsen MH, Fenckova M, . Disruption of POGZ Is Associated with Intellectual Disability and Autism Spectrum Disorders. Am J Hum Genet. 2016 Mar 3;98(3):541–52. doi: 10.1016/j.ajhg.2016.02.004. X-126942287
6235 Stevenson MT, Ghezzi PM, Valenton KG. FCT and delay fading for elopement with a child with autism. Behavior Analysis in Practice. 2016;9(2):169–73. doi: http://dx.doi.org/10.1007/s40617-015-0089-5. X-1, X-327606247
6236 Stevenson RA, Segers M, Ferber S, . Keeping time in the brain: Autism spectrum disorder and audiovisual temporal processing. Autism Res. 2016 Jul;9(7):720–38. doi: 10.1002/aur.1566. X-126402725
6237 Stevenson RA, Sun SZ, Hazlett N, . Seeing the Forest and the Trees: Default Local Processing in Individuals with High Autistic Traits Does Not Come at the Expense of Global Attention. J Autism Dev Disord. 2016 Feb 9 doi: 10.1007/s10803-016-2711-y. X-1
6238 Stewart E, Cancilliere MK, Freeman J, . Elevated Autism Spectrum Disorder Traits in Young Children with OCD. Child Psychiatry Hum Dev. 2016 Feb 8 doi: 10.1007/s10578-016-0629-4. X-1
6239 Stichter JP, Christ SE, Herzog MJ, . Exploring the role of executive functioning measures for social competence research. Assessment for Effective Intervention. 2016;41(4):243–54. doi: http://dx.doi.org/10.1177/1534508416644179. X-1
6240 Stichter JP, Herzog MJ, Owens SA, . Manualization, feasibility, and effectiveness of the school-based Social Competence Intervention for Adolescents (SCI-A). Psychology in the Schools. 2016;53(6):583–600. doi: http://dx.doi.org/10.1002/pits.21928. X-1, X-3
6241 Stokl J, Herzner G. Morphology and structure of the allomone and sex-pheromone producing mandibular gland of the parasitoid wasp Leptopilina heterotoma (Hymenoptera: Figitidae). Arthropod Struct Dev. 2016 Jun 24 doi: 10.1016/j.asd.2016.06.003. X-1
6242 Stoodley CJ, Limperopoulos C. Structure-function relationships in the developing cerebellum: Evidence from early-life cerebellar injury and neurodevelopmental disorders. Semin Fetal Neonatal Med. 2016 May 12 doi: 10.1016/j.siny.2016.04.010. X-1
6243 Storch EA, Nadeau JM, Johnco C, . Hoarding in youth with autism spectrum disorders and anxiety: Incidence, clinical correlates, and behavioral treatment response. Journal of Autism and Developmental Disorders. 2016;46(5):1602–12. doi: http://dx.doi.org/10.1007/s10803-015-2687-z. X-126749256
6244 Strom RG, Bae J, Mizutani J, . Lateral interbody fusion combined with open posterior surgery for adult spinal deformity. J Neurosurg Spine. 2016 Jun 24:1–9. doi: 10.3171/2016.4.spine16157. X-126360143
6245 Strunz S, Schermuck C, Ballerstein S, . Romantic Relationships and Relationship Satisfaction Among Adults With Asperger Syndrome and High-Functioning Autism. J Clin Psychol. 2016 May 16 doi: 10.1002/jclp.22319. X-1
6246 Stuttard L, Beresford B, Clarke S, . An evaluation of the Cygnet parenting support programme for parents of children with autism spectrum conditions. Research in Autism Spectrum Disorders. 2016;23:166–78. doi: http://dx.doi.org/10.1016/j.rasd.2015.12.004. X-1, X-4
6247 Su CC, Chi MH, Lin SH, . Bidirectional association between autism spectrum disorder and epilepsy in child and adolescent patients: a population-based cohort study. Eur Child Adolesc Psychiatry. 2016 Jan 20 doi: 10.1007/s00787-016-0817-6. X-1
6248 Sudarshan S, Gupta N, Kabra M. Genetic Studies in Autism. Indian J Pediatr. 2016 Mar 3 doi: 10.1007/s12098-015-1989-7. X-1, X-2
6249 Suess AN, Wacker DP, Schwartz JE, . Preliminary Evidence on the use of Telehealth in an Outpatient Behavior Clinic. J Appl Behav Anal. 2016 Mar 22 doi: 10.1002/jaba.305. X-1
6250 Sugimoto D, Bowen SL, Meehan WP, III, . Effects of neuromuscular training on children and young adults with Down syndrome: Systematic review and meta-analysis. Research in Developmental Disabilities. 2016;55:197–206. doi: http://dx.doi.org/10.1016/j.ridd.2016.04.003. X-127123540
6251 Sukasem C, Hongkaew Y, Ngamsamut N, . Impact of pharmacogenetic markers of CYP2D6 and DRD2 on prolactin response in risperidone-treated Thai children and adolescents with autism spectrum disorders. Journal of Clinical Psychopharmacology. 2016;36(2):141–6. doi: http://dx.doi.org/10.1097/JCP.0000000000000474. X-126872113
6252 Suma K, Adamson LB, Bakeman R, . After Early Autism Diagnosis: Changes in Intervention and Parent-Child Interaction. J Autism Dev Disord. 2016 May 18 doi: 10.1007/s10803-016-2808-3. X-1
6253 Suma K, Adamson LB, Bakeman R, . After early autism diagnosis: Changes in intervention and parent–child interaction. Journal of Autism and Developmental Disorders. 2016;46(8):2720–33. doi: http://dx.doi.org/10.1007/s10803-016-2808-3. X-127193183
6254 Sumner E, Leonard HC, Hill EL. Overlapping Phenotypes in Autism Spectrum Disorder and Developmental Coordination Disorder: A Cross-Syndrome Comparison of Motor and Social Skills. J Autism Dev Disord. 2016 Apr 28 doi: 10.1007/s10803-016-2794-5. X-1
6255 Sumner E, Pratt ML, Hill EL. Examining the cognitive profile of children with Developmental Coordination Disorder. Research in Developmental Disabilities. 2016;56:10–7. doi: http://dx.doi.org/10.1016/j.ridd.2016.05.012. X-127258924
6256 Sun C, Zou M, Zhao D, . Efficacy of Folic Acid Supplementation in Autistic Children Participating in Structured Teaching: An Open-Label Trial. Nutrients. 2016;8(6)doi: 10.3390/nu8060337.
6257 Sundelin HE, Larsson H, Lichtenstein P, . Autism and epilepsy: A population-based nationwide cohort study. Neurology. 2016 Jun 15 doi: 10.1212/wnl.0000000000002836. X-1
6258 Sutherland R, Trembath D, Hodge A, . Telehealth language assessments using consumer grade equipment in rural and urban settings: Feasible, reliable and well tolerated. J Telemed Telecare. 2016 Jan 13 doi: 10.1177/1357633x15623921. X-1
6259 Sy JR, Green L, Gratz O, . An Evaluation of the Effects of a Mild Delayed Verbal Punisher on Choice of an Immediate Reinforcer by Children With Autism. Behav Modif. 2016 Jan 12 doi: 10.1177/0145445515622382. X-1
6260 Syriopoulou-Delli CK, Cassimos DC, Polychronopoulou SA. Collaboration between teachers and parents of children with ASD on issues of education. Res Dev Disabil. 2016 May 24;55:330–45. doi: 10.1016/j.ridd.2016.04.011. X-127235770
6261 Szatmari P, Chawarska K, Dawson G, . Prospective longitudinal studies of infant siblings of children with autism: Lessons learned and future directions. Journal of the American Academy of Child & Adolescent Psychiatry. 2016;55(3):179–87. doi: http://dx.doi.org/10.1016/j.jaac.2015.12.014. X-126903251
6262 Tadayyon H, Sannachi L, Gangeh M, . Quantitative ultrasound assessment of breast tumor response to chemotherapy using a multi-parameter approach. Oncotarget. 2016 Apr 20 doi: 10.18632/oncotarget.8862. X-1
6263 Tager-Flusberg H, Plesa Skwerer D, Joseph RM, . Conducting research with minimally verbal participants with autism spectrum disorder. Autism. 2016 Jun 26 doi: 10.1177/1362361316654605. X-1
6264 Taheri A, Perry A, Minnes P. Examining the social participation of children and adolescents with Intellectual Disabilities and Autism Spectrum Disorder in relation to peers. Journal of Intellectual Disability Research. 2016;60(5):435–43. doi: http://dx.doi.org/10.1111/jir.12289. X-127120987
6265 Tait K, Fung F, Hu A, . Understanding Hong Kong Chinese families’ experiences of an autism/ASD diagnosis. Journal of Autism and Developmental Disorders. 2016;46(4):1164–83. doi: http://dx.doi.org/10.1007/s10803-015-2650-z. X-126572657
6266 Takahashi K, Miyatake N, Kurato R, . Prevalence of attention deficit hyperactivity disorder and/or autism spectrum disorder and its relation to lifestyle in female college students. Environ Health Prev Med. 2016 Jun 27 doi: 10.1007/s12199-016-0548-9. X-1
6267 Takahashi T, Yoshimura Y, Hiraishi H, . Enhanced brain signal variability in children with autism spectrum disorder during early childhood. Human Brain Mapping. 2016;37(3):1038–50. doi: http://dx.doi.org/10.1002/hbm.23089. X-126859309
6268 Takarae Y, Sablich SR, White SP, . Neurophysiological hyperresponsivity to sensory input in autism spectrum disorders. J Neurodev Disord. 2016;8:29. doi: 10.1186/s11689-016-9162-9. X-127504143
6269 Takemoto M, Boissiere L, Novoa F, . Sagittal malalignment has a significant association with postoperative leg pain in adult spinal deformity patients. Eur Spine J. 2016 May 25 doi: 10.1007/s00586-016-4616-z. X-1
6270 Talbott MR, Nelson CA, Tager-Flusberg H. Maternal vocal feedback to 9-month-old infant siblings of children with ASD. Autism Research. 2016;9(4):460–70. doi: http://dx.doi.org/10.1002/aur.1521. X-126174704
6271 Tamm G, Kreegipuu K, Harro J. Perception of emotion in facial stimuli: The interaction of ADRA2A and COMT genotypes, and sex. Prog Neuropsychopharmacol Biol Psychiatry. 2016 Jan 4;64:87–95. doi: 10.1016/j.pnpbp.2015.07.012. X-126234518
6272 Tan BW, Pooley JA, Speelman CP. A Meta-Analytic Review of the Efficacy of Physical Exercise Interventions on Cognition in Individuals with Autism Spectrum Disorder and ADHD. J Autism Dev Disord. 2016 Sep;46(9):3126–43. doi: 10.1007/s10803-016-2854-x. X-127412579
6273 Tan W, Schauder C, Naryshkina T, . Zfrp8 forms a complex with fragile-X mental retardation protein and regulates its localization and function. Dev Biol. 2016 Feb 15;410(2):202–12. doi: 10.1016/j.ydbio.2015.12.008. X-126772998
6274 Tanaka JW, Simonyi D. The “parts and wholes” of face recognition: A review of the literature. Q J Exp Psychol (Hove). 2016 Mar 4:1–14. doi: 10.1080/17470218.2016.1146780. X-1, X-2
6275 Tang X, Kim J, Zhou L, . KCC2 rescues functional deficits in human neurons derived from patients with Rett syndrome. Proc Natl Acad Sci U S A. 2016 Jan 19;113(3):751–6. doi: 10.1073/pnas.1524013113. X-126733678
6276 Tao Y, Gao H, Ackerman B, . Evidence for contribution of common genetic variants within chromosome 8p21.2–8p21.1 to restricted and repetitive behaviors in autism spectrum disorders. BMC Genomics. 2016;17:163. doi: 10.1186/s12864-016-2475-y. X-126931105
6277 Tasse MJ, Schalock RL, Thissen D, . Development and Standardization of the Diagnostic Adaptive Behavior Scale: Application of Item Response Theory to the Assessment of Adaptive Behavior. Am J Intellect Dev Disabil. 2016 Mar;121(2):79–94. doi: 10.1352/1944-7558-121.2.79. X-126914464
6278 Tavassoli T, Bellesheim K, Siper PM, . Measuring Sensory Reactivity in Autism Spectrum Disorder: Application and Simplification of a Clinician-Administered Sensory Observation Scale. J Autism Dev Disord. 2016 Jan;46(1):287–93. doi: 10.1007/s10803-015-2578-3. X-126340959
6279 Tavassoli T, Bellesheim K, Tommerdahl M, . Altered tactile processing in children with autism spectrum disorder. Autism Res. 2016 Jun;9(6):616–20. doi: 10.1002/aur.1563. X-126568449
6280 Taylor CE, Bush K. Unintended consequences of inhibiting dihydrofolate reductase through folic acid supplementation: inattentive-type attention deficit hyperactivity disorder and ASD connections. Int J Food Sci Nutr. 2016 Jun 26:1–2. doi: 10.1080/09637486.2016.1200017. X-1
6281 Taylor LS, Zhang GG. Physical chemistry of supersaturated solutions and implications for oral absorption. Adv Drug Deliv Rev. 2016 Jun 1;101:122–42. doi: 10.1016/j.addr.2016.03.006. X-127013254
6282 Taylor MJ, Lichtenstein P, Larsson H, . Is there a female protective effect against attention-deficit/hyperactivity disorder? Evidence from two representative twin samples. Journal of the American Academy of Child & Adolescent Psychiatry. 2016;55(6):504–12. doi: http://dx.doi.org/10.1016/j.jaac.2016.04.004. X-127238069
6283 Tede Z, Cohen MO, Riskin A, . The reliability and validity of the Greenspan Social Emotional Growth Chart (GSEGC) in Israeli children with developmental delay and autism—A pilot study. Research in Developmental Disabilities. 2016;55:226–34. doi: http://dx.doi.org/10.1016/j.ridd.2016.04.013. X-127138232
6284 Tede Z, Ophir Cohen M, Riskin A, . The reliability and validity of the Greenspan Social Emotional Growth Chart (GSEGC) in Israeli children with developmental delay and autism-A pilot study. Res Dev Disabil. 2016 Apr 30;55:226–34. doi: 10.1016/j.ridd.2016.04.013. X-127138232
6285 Teng BL, Nikolova VD, Riddick NV, . Reversal of social deficits by subchronic oxytocin in two autism mouse models. Neuropharmacology. 2016 Jun;105:61–71. doi: 10.1016/j.neuropharm.2015.12.025. X-126748053
6286 Terzi A, Marinis T, Francis K. The Interface of Syntax with Pragmatics and Prosody in Children with Autism Spectrum Disorders. J Autism Dev Disord. 2016 May 21 doi: 10.1007/s10803-016-2811-8. X-1
6287 Than KD, Park P, Fu KM, . Clinical and radiographic parameters associated with best versus worst clinical outcomes in minimally invasive spinal deformity surgery. J Neurosurg Spine. 2016 Jul;25(1):21–5. doi: 10.3171/2015.12.spine15999. X-126943254
6288 Thapa R. Retrospective descriptive study of cerebral palsy in Nepal. Journal of Autism and Developmental Disorders. 2016;46(7):2285–91. doi: http://dx.doi.org/10.1007/s10803-016-2757-x. X-126944590
6289 Theoharides TC, Tsilioni I, Patel AB, . Atopic diseases and inflammation of the brain in the pathogenesis of autism spectrum disorders. Transl Psychiatry. 2016;6(6):e844. doi: 10.1038/tp.2016.77. X-127351598
6290 Theologis AA, Ailon T, Scheer JK, . Impact of preoperative depression on 2-year clinical outcomes following adult spinal deformity surgery: the importance of risk stratification based on type of psychological distress. J Neurosurg Spine. 2016 May 6:1–9. doi: 10.3171/2016.2.spine15980. X-1
6291 Theologis AA, Miller L, Callahan M, . The Economic Impact of Revision Surgery for Proximal Junctional Failure after Adult Spinal Deformity Surgery: A Cost Analysis of 57 Operations in A 10-Year Experience at a Major Deformity Center. Spine (Phila Pa 1976). 2016 Feb 18 doi: 10.1097/brs.0000000000001523. X-1
6292 Therrien MC, Light J, Pope L. Systematic Review of the Effects of Interventions to Promote Peer Interactions for Children who use Aided AAC. Augment Altern Commun. 2016 Jun;32(2):81–93. doi: 10.3109/07434618.2016.1146331. X-1, X-226903484
6293 Thomas BL, Viljoen M. EEG brain wave activity at rest and during evoked attention in children with attention-deficit/hyperactivity disorder and effects of methylphenidate. Neuropsychobiology. 2016;73(1):16–22. doi: http://dx.doi.org/10.1159/000441523. X-126812442
6294 Thomas MSC, Davis R, Karmiloff-Smith A, . The over-pruning hypothesis of autism. Developmental Science. 2016;19(2):284–305. doi: http://dx.doi.org/10.1111/desc.12303. X-125845529
6295 Thomas RE, Spragins W, Mazloum G, . Rates of detection of developmental problems at the 18-month well-baby visit by family physicians’ using four evidence-based screening tools compared to usual care: A randomized controlled trial. Child: Care, Health and Development. 2016;42(3):382–93. doi: http://dx.doi.org/10.1111/cch.12333. X-1
6296 Thorup E, Nystrom P, Gredeback G, . Altered gaze following during live interaction in infants at risk for autism: an eye tracking study. Mol Autism. 2016;7:12. doi: 10.1186/s13229-016-0069-9. X-126819699
6297 Thurm A, Himelstein D, D’Souza P, . Creatine transporter deficiency: Screening of males with neurodevelopmental disorders and neurocognitive characterization of a case. Journal of Developmental and Behavioral Pediatrics. 2016;37(4):322–6. doi: http://dx.doi.org/10.1097/DBP.0000000000000299. X-127096572
6298 Thurm A, Tierney E, Farmer C, . Development, behavior, and biomarker characterization of Smith-Lemli-Opitz syndrome: an update. J Neurodev Disord. 2016;8:12. doi: 10.1186/s11689-016-9145-x. X-127053961
6299 Tian W, Yan K, Han X, . Comparison of the Clinical and Radiographic Results between Cervical Artificial Disc Replacement and Anterior Cervical Fusion: A Six-year Prospective Non-randomized Comparative Study. Clin Spine Surg. 2016 Jun 28 doi: 10.1097/bsd.0000000000000206. X-1
6300 Tian Y, Wang L, Jia M, . Association of oligodendrocytes differentiation regulator gene DUSP15 with autism. World J Biol Psychiatry. 2016 May 25:1–8. doi: 10.1080/15622975.2016.1178395. X-1
6301 Tick B, Bolton P, Happé F, . Heritability of autism spectrum disorders: A meta-analysis of twin studies. Journal of Child Psychology and Psychiatry. 2016;57(5):585–95. doi: http://dx.doi.org/10.1111/jcpp.12499. X-126709141
6302 Tick B, Colvert E, McEwen F, . Autism spectrum disorders and other mental health problems: Exploring etiological overlaps and phenotypic causal associations. Journal of the American Academy of Child & Adolescent Psychiatry. 2016;55(2):106–13. doi: http://dx.doi.org/10.1016/j.jaac.2015.11.013. X-126802777
6303 Timmons L, Willis KD, Pruitt MM, . Predictors of Daily Relationship Quality in Mothers of Children with Autism Spectrum Disorder. J Autism Dev Disord. 2016 Apr 20 doi: 10.1007/s10803-016-2799-0. X-1
6304 Timonen-Soivio L, Vanhala R, Malm H, . Brief Report: Syndromes in Autistic Children in a Finnish Birth Cohort. J Autism Dev Disord. 2016 Apr 21 doi: 10.1007/s10803-016-2789-2. X-1
6305 Tint A, Maughan AL, Weiss JA. Community participation of youth with intellectual disability and autism spectrum disorder. J Intellect Disabil Res. 2016 Aug 4 doi: 10.1111/jir.12311. X-1
6306 Tirado MJ, Saldaña D. Readers with autism can produce inferences, but they cannot answer inferential questions. Journal of Autism and Developmental Disorders. 2016;46(3):1025–37. doi: http://dx.doi.org/10.1007/s10803-015-2648-6. X-126547920
6307 Tomeny TS. Parenting stress as an indirect pathway to mental health concerns among mothers of children with autism spectrum disorder. Autism. 2016 Jul 1 doi: 10.1177/1362361316655322. X-1
6308 Tong HJ, Lee HY, Lee YT, . Factors influencing the inclusion of oral health education in individualized education plans of children with autism spectrum disorders in Singapore. Int J Paediatr Dent. 2016 Aug 1 doi: 10.1111/ipd.12257. X-1
6309 Torelli JN, Lambert JM, Da Fonte MA, . Assessing acquisition of and preference for mand topographies during functional communication training. Behavior Analysis in Practice. 2016;9(2):165–8. doi: http://dx.doi.org/10.1007/s40617-015-0083-y. X-1, X-3, X-427606246
6310 Torras-Mañá M, Gómez-Morales A, González-Gimeno I, . Assessment of cognition and language in the early diagnosis of autism spectrum disorder: Usefulness of the Bayley Scales of infant and toddler development, third edition. Journal of Intellectual Disability Research. 2016;60(5):502–11. doi: http://dx.doi.org/10.1111/jir.12291. X-127120991
6311 Torres EB, Nguyen J, Mistry S, . Characterization of the Statistical Signatures of Micro-Movements Underlying Natural Gait Patterns in Children with Phelan McDermid Syndrome: Towards Precision-Phenotyping of Behavior in ASD. Front Integr Neurosci. 2016;10:22. doi: 10.3389/fnint.2016.00022. X-127445720
6312 Torrico B, Chiocchetti AG, Bacchelli E, . Lack of replication of previous autism spectrum disorder GWAS hits in European populations. Autism Res. 2016 Jul 15 doi: 10.1002/aur.1662. X-1
6313 Toussaint KA, Kodak T, Vladescu JC. An evaluation of choice on instructional efficacy and individual preferences among children with autism. Journal of Applied Behavior Analysis. 2016;49(1):170–5. doi: http://dx.doi.org/10.1002/jaba.263. X-1, X-3, X-426510978
6314 Tovo-Rodrigues L, Recamonde-Mendoza M, Paixao-Cortes VR, . The role of protein intrinsic disorder in major psychiatric disorders. Am J Med Genet B Neuropsychiatr Genet. 2016 May 17 doi: 10.1002/ajmg.b.32455. X-1
6315 Traboulsi EI, Vanderveen D, Morrison D, . Associated systemic and ocular disorders in patients with congenital unilateral cataracts: the Infant Aphakia Treatment Study experience. Eye (Lond). 2016 Jun 17 doi: 10.1038/eye.2016.124. X-1
6316 Tran NN, Pham TT, Ozawa K, . Impacts of Perinatal Dioxin Exposure on Motor Coordination and Higher Cognitive Development in Vietnamese Preschool Children: A Five-Year Follow-Up. PLoS One. 2016;11(1):e0147655. doi: 10.1371/journal.pone.0147655. X-126824471
6317 Trasande L, Zoeller RT, Hass U, . Burden of disease and costs of exposure to endocrine disrupting chemicals in the European Union: an updated analysis. Andrology. 2016 Mar 22 doi: 10.1111/andr.12178. X-1
6318 Travers BG, Bigler ED, Duffield TC, . Longitudinal development of manual motor ability in autism spectrum disorder from childhood to mid-adulthood relates to adaptive daily living skills. Dev Sci. 2016 Apr 7 doi: 10.1111/desc.12401. X-1
6319 Trembath D, Hawtree R, Arciuli J, . What do speech-language pathologists think parents expect when treating their children with autism spectrum disorder? Int J Speech Lang Pathol. 2016 Jun;18(3):250–8. doi: 10.3109/17549507.2016.1139625. X-127063700
6320 Trimmer E, McDonald S, Rushby JA. Not knowing what I feel: Emotional empathy in autism spectrum disorders. Autism. 2016 May 30 doi: 10.1177/1362361316648520. X-1
6321 Tropeano M, Howley D, Gazzellone MJ, . Microduplications at the pseudoautosomal SHOX locus in autism spectrum disorders and related neurodevelopmental conditions. J Med Genet. 2016 Apr 12 doi: 10.1136/jmedgenet-2015-103621. X-1
6322 Trotter PD, McGlone F, McKie S, . Effects of acute tryptophan depletion on central processing of CT-targeted and discriminatory touch in humans. Eur J Neurosci. 2016 Jun 16 doi: 10.1111/ejn.13298. X-1
6323 Troyb E, Knoch K, Herlihy L, . Restricted and repetitive behaviors as predictors of outcome in autism spectrum disorders. Journal of Autism and Developmental Disorders. 2016;46(4):1282–96. doi: http://dx.doi.org/10.1007/s10803-015-2668-2. X-126676629
6324 Truszkowski TL, James EJ, Hasan M, . Fragile X mental retardation protein knockdown in the developing Xenopus tadpole optic tectum results in enhanced feedforward inhibition and behavioral deficits. Neural Dev. 2016;11(1):14. doi: 10.1186/s13064-016-0069-7. X-127503008
6325 Truzzi A, Setoh P, Shinohara K, . Physiological responses to dyadic interactions are influenced by neurotypical adults’ levels of autistic and empathy traits. Physiol Behav. 2016 Jun 28;165:7–14. doi: 10.1016/j.physbeh.2016.06.034. X-127371501
6326 Tsai PT. Autism and cerebellar dysfunction: Evidence from animal models. Semin Fetal Neonatal Med. 2016 May 11 doi: 10.1016/j.siny.2016.04.009. X-1
6327 Tseng A, Wang Z, Huo Y, . Differences in neural activity when processing emotional arousal and valence in autism spectrum disorders. Human Brain Mapping. 2016;37(2):443–61. doi: http://dx.doi.org/10.1002/hbm.23041. X-126526072
6328 Tseng KC, Tseng SH, Cheng HY. Design, development, and clinical validation of therapeutic toys for autistic children. J Phys Ther Sci. 2016 Jul;28(7):1972–80. doi: 10.1589/jpts.28.1972. X-127512246
6329 Tu PC, Hsu JW, Lan CC, . Structural and functional correlates of a quantitative autistic trait measured using the social responsive scale in neurotypical male adolescents. Autism Research. 2016;9(5):570–8. doi: http://dx.doi.org/10.1002/aur.1535. X-126284955
6330 Turcotte P, Mathew M, Shea LL, . Service needs across the lifespan for individuals with autism. Journal of Autism and Developmental Disorders. 2016;46(7):2480–9. doi: http://dx.doi.org/10.1007/s10803-016-2787-4. X-127084080
6331 Türkoğlu S, Türkoğlu G. Comorbid gender dysphoria in a preadolescent boy with fragile X syndrome. Archives of Sexual Behavior. 2016;45(4):791–2. doi: http://dx.doi.org/10.1007/s10508-016-0710-x. X-126883024
6332 Turner AH, Greenspan KS, van Erp TG. Pallidum and lateral ventricle volume enlargement in autism spectrum disorder. Psychiatry Res. 2016 Jun 30;252:40–5. doi: 10.1016/j.pscychresns.2016.04.003. X-127179315
6333 Turner JD, Eastlack RK, Mirzadeh Z, . Fluctuations in Spinal Cord Perfusion During Adult Spinal Deformity Correction Identify Neurologic Changes: Proof of Concept. World Neurosurg. 2016 Jan;85:365.e1–6. doi: 10.1016/j.wneu.2015.08.067. X-1
6334 Turner TN, Hormozdiari F, Duyzend MH, . Genome Sequencing of Autism-Affected Families Reveals Disruption of Putative Noncoding Regulatory DNA. Am J Hum Genet. 2016 Jan 7;98(1):58–74. doi: 10.1016/j.ajhg.2015.11.023. X-126749308
6335 Turner-Brown L, Hume K, Boyd BA, . Preliminary Efficacy of Family Implemented TEACCH for Toddlers: Effects on Parents and Their Toddlers with Autism Spectrum Disorder. J Autism Dev Disord. 2016 May 30 doi: 10.1007/s10803-016-2812-7. X-1
6336 Tustin F. Revisiting Frances Tustin’s ‘Autistic processes’. Journal of Child Psychotherapy. 2016;42(1):54–68. doi: http://dx.doi.org/10.1080/0075417X.2016.1140924. X-1
6337 Tyner S, Brewer A, Helman M, . Nice doggie! Contact desensitization plus reinforcement decreases dog phobias for children with autism. Behavior Analysis in Practice. 2016;9(1):54–7. doi: http://dx.doi.org/10.1007/s40617-016-0113-4. X-1, X-3, X-427606239
6338 Ucak A, Temizkan V, Ugur M, . Comparison of primary repair and patch plasty procedure on the P wave in adult atrial septal defect closure. Cardiovasc J Afr. 2016 May 4;27:1–4. doi: 10.5830/cvja-2016-013. X-1
6339 Uemura H. Surgical aspects of atrial arrhythmia : Right atrial ablation and anti-arrhythmic surgery in congenital heart disease. Herzschrittmacherther Elektrophysiol. 2016 Jun;27(2):137–42. doi: 10.1007/s00399-016-0434-6. X-127225164
6340 Ulbrich L, Favaloro FL, Trobiani L, . Autism-associated R451C mutation in neuroligin3 leads to activation of the unfolded protein response in a PC12 Tet-On inducible system. Biochem J. 2016 Feb 15;473(4):423–34. doi: 10.1042/bj20150274. X-126621873
6341 Uljarevic M, Carrington S, Leekam S. Brief Report: Effects of Sensory Sensitivity and Intolerance of Uncertainty on Anxiety in Mothers of Children with Autism Spectrum Disorder. J Autism Dev Disord. 2016 Jan;46(1):315–9. doi: 10.1007/s10803-015-2557-8. X-126254895
6342 Uljarevic M, Evans DW. Relationship between repetitive behaviour and fear across normative development, autism spectrum disorder, and down syndrome. Autism Res. 2016 Jul 26 doi: 10.1002/aur.1674. X-1
6343 Uljarevic M, Katsos N, Hudry K, . Practitioner Review: Multilingualism and neurodevelopmental disorders - an overview of recent research and discussion of clinical implications. J Child Psychol Psychiatry. 2016 Jul 22 doi: 10.1111/jcpp.12596. X-1
6344 Uljarevic M, Lane A, Kelly A, . Sensory subtypes and anxiety in older children and adolescents with autism spectrum disorder. Autism Res. 2016 Jan 13 doi: 10.1002/aur.1602. X-1
6345 Ung D, Johnco C, McBride NM, . Optimizing the screening of autism spectrum disorders in outpatient clinics: An examination of the Social Communication Questionnaire-Lifetime. Research in Autism Spectrum Disorders. 2016;27:21–8. doi: http://dx.doi.org/10.1016/j.rasd.2016.03.011. X-1
6346 Unterrainer JM, Rauh R, Rahm B, . Development of planning in children with high-functioning autism spectrum disorders and/or attention deficit/hyperactivity disorder. Autism Research. 2016;9(7):739–51. doi: http://dx.doi.org/10.1002/aur.1574. X-126442805
6347 Urbain C, Vogan VM, Ye AX, . Desynchronization of fronto-temporal networks during working memory processing in autism. Human Brain Mapping. 2016;37(1):153–64. doi: http://dx.doi.org/10.1002/hbm.23021. X-126485059
6348 Urbanowicz A, Leonard H, Girdler S, . Parental perspectives on the communication abilities of their daughters with Rett syndrome. Developmental Neurorehabilitation. 2016;19(1):17–25. doi: http://dx.doi.org/10.3109/17518423.2013.879940. X-124564222
6349 Usami M. Functional consequences of attention-deficit hyperactivity disorder on children and their families. Psychiatry and Clinical Neurosciences. 2016;70(8):303–17. doi: http://dx.doi.org/10.1111/pcn.12393. X-127061213
6350 Uzefovsky F, Allison C, Smith P, . Brief Report: The Go/No-Go Task Online: Inhibitory Control Deficits in Autism in a Large Sample. J Autism Dev Disord. 2016 Apr 21 doi: 10.1007/s10803-016-2788-3. X-1
6351 Vaillancourt T, Haltigan JD, Smith I, . Joint trajectories of internalizing and externalizing problems in preschool children with autism spectrum disorder. Dev Psychopathol. 2016 Feb 5:1–12. doi: 10.1017/s0954579416000043. X-1
6352 Valenzuela CF, Medina AE, Wozniak JR, . Proceedings of the 2015 Annual Meeting of the Fetal Alcohol Spectrum Disorders Study Group. Alcohol. 2016;50:37–42. doi: http://dx.doi.org/10.1016/j.alcohol.2015.10.002. X-126695590
6353 Valvo G, Baldini S, Retico A, . Temporal lobe connects regression and macrocephaly to autism spectrum disorders. European Child & Adolescent Psychiatry. 2016;25(4):421–9. doi: http://dx.doi.org/10.1007/s00787-015-0746-9. X-1, X-326224585
6354 van Amen-Hellebrekers CJ, Jansen S, Pfundt R, . Duplications of SLC1A3: Associated with ADHD and autism. Eur J Med Genet. 2016 Jun 11;59(8):373–6. doi: 10.1016/j.ejmg.2016.06.003. X-127296938
6355 van Boxtel JJ, Dapretto M, Lu H. Intact recognition, but attenuated adaptation, for biological motion in youth with autism spectrum disorder. Autism Res. 2016 Jan 25 doi: 10.1002/aur.1595. X-1
6356 van den Heuvel L, Suliman S, Malan-Muller S, . Brain-derived neurotrophic factor Val66met polymorphism and plasma levels in road traffic accident survivors. Anxiety Stress Coping. 2016 Mar 29:1–14. doi: 10.1080/10615806.2016.1163545. X-125616421
6357 Van der Hallen R, Evers K, Boets B, . Visual Search in ASD: Instructed Versus Spontaneous Local and Global Processing. J Autism Dev Disord. 2016 Jun 22 doi: 10.1007/s10803-016-2826-1. X-1
6358 van der Steen SL, Riedijk SR, Verhagen-Visser J, . The Psychological Impact of Prenatal Diagnosis and Disclosure of Susceptibility Loci: First Impressions of Parents’ Experiences. J Genet Couns. 2016 May 25 doi: 10.1007/s10897-016-9960-y. X-1
6359 van Goozen SHM, Langley K, Northover C, . Identifying mechanisms that underlie links between COMT genotype and aggression in male adolescents with ADHD. Journal of Child Psychology and Psychiatry. 2016;57(4):472–80. doi: http://dx.doi.org/10.1111/jcpp.12464. X-126395975
6360 van IMH, Bakermans-Kranenburg MJ. The Role of Oxytocin in Parenting and as Augmentative Pharmacotherapy: Critical Issues and Bold Conjectures. J Neuroendocrinol. 2016 Aug;28(8)doi: 10.1111/jne.12355. X-1
6361 van Schalkwyk GI, Beyer C, Martin A, . College students with Autism Spectrum Disorders: A growing role for adult psychiatrists. J Am Coll Health. 2016 Jun 27:0. doi: 10.1080/07448481.2016.1205072. X-1
6362 van Scheppingen J, Iyer AM, Prabowo AS, . Expression of microRNAs miR21, miR146a, and miR155 in tuberous sclerosis complex cortical tubers and their regulation in human astrocytes and SEGA-derived cell cultures. Glia. 2016 Jun;64(6):1066–82. doi: 10.1002/glia.22983. X-127014996
6363 van Scheppingen J, Iyer AM, Prabowo AS, . Expression of microRNAs miR21, miR146a, and miR155 in tuberous sclerosis complex cortical tubers and their regulation in human astrocytes and SEGA-derived cell cultures. Glia. 2016;64(6):1066–82. doi: http://dx.doi.org/10.1002/glia.22983. X-127014996
6364 Vanegas SB, Magaña S, Morales M, . Clinical validity of the ADI-R in a US-Based Latino population. Journal of Autism and Developmental Disorders. 2016;46(5):1623–35. doi: http://dx.doi.org/10.1007/s10803-015-2690-4. X-126742934
6365 Vanmarcke S, Mullin C, Van der Hallen R, . In the Eye of the Beholder: Rapid Visual Perception of Real-Life Scenes by Young Adults with and Without ASD. J Autism Dev Disord. 2016 Apr 28 doi: 10.1007/s10803-016-2802-9. X-1
6366 Vanvuchelen M. A qualitative analysis of imitation performances of preschoolers with Down syndrome. American Journal on Intellectual and Developmental Disabilities. 2016;121(3):266–75. doi: http://dx.doi.org/10.1352/1944-7558-121.3.266. X-127119215
6367 Vanvuchelen M, Van Schuerbeeck L, Braeken MA. Screening accuracy of the parent-completed Ages and Stages Questionnaires - second edition as a broadband screener for motor problems in preschoolers with autism spectrum disorders. Autism. 2016 Feb 5 doi: 10.1177/1362361315621703. X-1
6368 Vanwong N, Ngamsamut N, Medhasi S, . Impact of CYP2D6 Polymorphism on Steady-State Plasma Levels of Risperidone and 9-Hydroxyrisperidone in Thai Children and Adolescents with Autism Spectrum Disorder. J Child Adolesc Psychopharmacol. 2016 Jan 18 doi: 10.1089/cap.2014.0171. X-1
6369 Vanwong N, Prommas S, Puangpetch A, . Development and Validation of Liquid Chromatography/Tandem Mass Spectrometry Analysis for Therapeutic Drug Monitoring of Risperidone and 9-Hydroxyrisperidone in Pediatric Patients with Autism Spectrum Disorders. J Clin Lab Anal. 2016 Jun 26 doi: 10.1002/jcla.22009. X-1
6370 Varcin KJ, Nelson CA, III, Ko J, . Visual evoked potentials as a readout of cortical function in infants with tuberous sclerosis complex. Journal of Child Neurology. 2016;31(2):195–202. doi: http://dx.doi.org/10.1177/0883073815587328. X-126018199
6371 Vargas S, Lucker JR. A Quantitative Summary of The Listening Program (TLP) Efficacy Studies: What Areas Were Found to Improve by TLP Intervention? Occup Ther Int. 2016 Jun;23(2):206–17. doi: 10.1002/oti.1425. X-126890280
6372 Vasli N, Ahmed I, Mittal K, . Identification of a homozygous missense mutation in LRP2 and a hemizygous missense mutation in TSPYL2 in a family with mild intellectual disability. Psychiatric Genetics. 2016;26(2):66–73. doi: http://dx.doi.org/10.1097/YPG.0000000000000114. X-126529358
6373 Veazey SE, Valentino AL, Low AI, . Teaching feminine hygiene skills to young females with autism spectrum disorder and intellectual disability. Behavior Analysis in Practice. 2016;9(2):184–9. doi: http://dx.doi.org/10.1007/s40617-015-0065-0. X-1, X-3, X-427606248
6374 Velott DL, Agbese E, Mandell D, . Medicaid 1915(c) Home- and Community-Based Services waivers for children with autism spectrum disorder. Autism. 2016;20(4):473–82. doi: http://dx.doi.org/10.1177/1362361315590806. X-126088059
6375 Venkataraman A, Yang D, Pelphrey K, . Bayesian Community Detection in the Space of Group-Level Functional Differences. IEEE Trans Med Imaging. 2016 Mar 2 doi: 10.1109/tmi.2016.2536559. X-1
6376 Venker CE. Spoken word recognition in children with autism spectrum disorder: The role of visual disengagement. Autism. 2016 Jun 22 doi: 10.1177/1362361316653230. X-1
6377 Venker CE, Haebig E, Edwards J, . Brief report: Early lexical comprehension in young children with ASD: Comparing eye-gaze methodology and parent report. Journal of Autism and Developmental Disorders. 2016;46(6):2260–6. doi: http://dx.doi.org/10.1007/s10803-016-2747-z. X-126883646
6378 Venker CE, Kover ST, Weismer SE. Brief report: Fast mapping predicts differences in concurrent and later language abilities among children with ASD. Journal of Autism and Developmental Disorders. 2016;46(3):1118–23. doi: http://dx.doi.org/10.1007/s10803-015-2644-x. X-126572655
6379 Ventola PE, Yang D, Abdullahi SM, . Brief Report: Reduced Restricted and Repetitive Behaviors after Pivotal Response Treatment. J Autism Dev Disord. 2016 May 26 doi: 10.1007/s10803-016-2813-6. X-3
6380 Verhaeghe L, Dereu M, Warreyn P, . Erratum to: Extremely Preterm Born Children at Very High Risk for Developing Autism Spectrum Disorder. Child Psychiatry Hum Dev. 2016 Apr 30 doi: 10.1007/s10578-016-0647-2. X-1
6381 Vernon TW, Miller AR, Ko JA, . Social tools and rules for teens (The START program): Program description and preliminary outcomes of an experiential socialization intervention for adolescents with autism spectrum disorder. Journal of Autism and Developmental Disorders. 2016;46(5):1806–23. doi: http://dx.doi.org/10.1007/s10803-016-2715-7. X-1, X-3, X-426861720
6382 Verpeut JL, DiCicco-Bloom E, Bello NT. Ketogenic diet exposure during the juvenile period increases social behaviors and forebrain neural activation in adult Engrailed 2 null mice. Physiol Behav. 2016 Jul 1;161:90–8. doi: 10.1016/j.physbeh.2016.04.001. X-127080080
6383 Verriden AL, Roscoe EM. A comparison of preference-assessment methods. Journal of Applied Behavior Analysis. 2016;49(2):265–85. doi: http://dx.doi.org/10.1002/jaba.302. X-127037669
6384 Vicidomini C, Ponzoni L, Lim D, . Pharmacological enhancement of mGlu5 receptors rescues behavioral deficits in SHANK3 knock-out mice. Mol Psychiatry. 2016 Mar 29 doi: 10.1038/mp.2016.30. X-1
6385 Vied C, Ray S, Badger CD, . Transcriptomic analysis of the hippocampus from six inbred strains of mice suggests basis for sex-specific susceptibility and severity of neurological disorders. J Comp Neurol. 2016 Feb 24 doi: 10.1002/cne.23989. X-1
6386 Virring A, Lambek R, Thomsen PH, . Disturbed sleep in attention-deficit hyperactivity disorder (ADHD) is not a question of psychiatric comorbidity or ADHD presentation. Journal of Sleep Research. 2016;25(3):333–40. doi: http://dx.doi.org/10.1111/jsr.12377. X-126762193
6387 Visser JC, Rommelse NN, Greven CU, . Autism spectrum disorder and attention-deficit/hyperactivity disorder in early childhood: A review of unique and shared characteristics and developmental antecedents. Neurosci Biobehav Rev. 2016 Jun;65:229–63. doi: 10.1016/j.neubiorev.2016.03.019. X-127026637
6388 Vittori M, Tusek-Znidaric M, Strus J. Exoskeletal cuticle of cavernicolous and epigean terrestrial isopods: A review and perspectives. Arthropod Struct Dev. 2016 Aug 5 doi: 10.1016/j.asd.2016.08.002. X-1
6389 Vivanti G, Dissanayake C. Outcome for Children Receiving the Early Start Denver Model Before and After 48 Months. J Autism Dev Disord. 2016 Jul;46(7):2441–9. doi: 10.1007/s10803-016-2777-6. X-327020055
6390 Vogan VM, Morgan BR, Leung RC, . Widespread white matter differences in children and adolescents with autism spectrum disorder. Journal of Autism and Developmental Disorders. 2016;46(6):2138–47. doi: http://dx.doi.org/10.1007/s10803-016-2744-2. X-126899725
6391 Voigt V, Neufeld F, Kaste J, . Clinically assessed posttraumatic stress in patients with breast cancer during the first year after diagnosis in the prospective, longitudinal, controlled COGNICARES study. Psychooncology. 2016 Feb 22 doi: 10.1002/pon.4102. X-1
6392 Volkmann RA, Fanger CM, Anderson DR, . MPX-004 and MPX-007: New Pharmacological Tools to Study the Physiology of NMDA Receptors Containing the GluN2A Subunit. PLoS One. 2016;11(2):e0148129. doi: 10.1371/journal.pone.0148129. X-126829109
6393 Vollebregt MA, Zumer JM, ter Huurne N, . Posterior alpha oscillations reflect attentional problems in boys with Attention Deficit Hyperactivity Disorder. Clinical Neurophysiology. 2016;127(5):2182–91. doi: http://dx.doi.org/10.1016/j.clinph.2016.01.021. X-127072088
6394 Vomund S, de Souza Silva MA, Huston JP, . Behavioral Resilience and Sensitivity to Locally Restricted Cortical Migration Deficits Induced by In Utero Knockdown of Disabled-1 in the Adult Rat. Cereb Cortex. 2016 Mar 10 doi: 10.1093/cercor/bhw060. X-1
6395 Voon V, Dalley JW. Translatable and Back-Translatable Measurement of Impulsivity and Compulsivity: Convergent and Divergent Processes. Curr Top Behav Neurosci. 2016 Jul 15 doi: 10.1007/7854_2015_5013. X-1
6396 Wade MG, Tsai C-L, Stoffregen T, . Perception of object length via manual wielding in children with and without developmental coordination disorder. Journal of Motor Behavior. 2016;48(1):13–9. doi: http://dx.doi.org/10.1080/00222895.2015.1025902. X-1, X-325927247
6397 Wainer AL, Hepburn S, McMahon Griffith E. Remembering parents in parent-mediated early intervention: An approach to examining impact on parents and families. Autism. 2016 Mar 7 doi: 10.1177/1362361315622411. X-1
6398 Waite J, Beck SR, Heald M, . Dissociation of cross-sectional trajectories for verbal and visuo-spatial working memory development in Rubinstein-Taybi syndrome. Journal of Autism and Developmental Disorders. 2016;46(6):2064–71. doi: http://dx.doi.org/10.1007/s10803-016-2736-2. X-127011324
6399 Walerius DM, Fogleman ND, Rosen PJ. The role of ADHD and negative emotional lability in predicting changes in parenting daily hassles. Journal of Child and Family Studies. 2016;25(7):2279–91. doi: http://dx.doi.org/10.1007/s10826-016-0381-1. X-1
6400 Wallace C, Ievers-Landis CE, Scherer C, . Attention-deficit/hyperactivity disorder, behavior regulation and virtual school support. Journal of Developmental and Behavioral Pediatrics. 2016;37(3):254–6. doi: http://dx.doi.org/10.1097/DBP.0000000000000292. X-127035698
6401 Wallace GL, Budgett J, Charlton RA. Aging and autism spectrum disorder: Evidence from the broad autism phenotype. Autism Res. 2016 Mar 11 doi: 10.1002/aur.1620. X-1
6402 Walton KM, Ingersoll BR. The utility of Thin Slice ratings for predicting language growth in children with autism spectrum disorder. Autism. 2016;20(3):374–80. doi: http://dx.doi.org/10.1177/1362361315584465. X-125991846
6403 Wan SH, McKie PM, Schirger JA, . Chronic Peptide Therapy With B-Type Natriuretic Peptide in Patients With Pre-Clinical Diastolic Dysfunction (Stage B Heart Failure). JACC Heart Fail. 2016 Jul;4(7):539–47. doi: 10.1016/j.jchf.2015.12.014. X-126874387
6404 Wang AT, Lim T, Jamison J, . Neural selectivity for communicative auditory signals in Phelan-McDermid syndrome. Journal of Neurodevelopmental Disorders. 2016;8 doi: http://dx.doi.org/10.1186/s11689-016-9138-9. X-126981159
6405 Wang H, Lee IS, Braun C, . Effect of probiotics on central nervous system functions in animals and humans - a systematic review. J Neurogastroenterol Motil. 2016 Jul 13 doi: 10.5056/jnm16018. X-1
6406 Wang H, Liang S, Wang M, . Potential serum biomarkers from a metabolomics study of autism. Journal of Psychiatry & Neuroscience. 2016;41(1):27–37. doi: http://dx.doi.org/10.1503/jpn.140009. X-126395811
6407 Wang HG, Jeffries JJ, Wang TF. Genetic and developmental perspective of language abnormality in autism and schizophrenia: One disease occurring at different ages in humans? The Neuroscientist. 2016;22(2):119–31. doi: http://dx.doi.org/10.1177/1073858415572078. X-125686622
6408 Wang KY. Updated findings on neurodevelopmental disorders in Taiwan: impact of the institutionalized national healthcare system on prevalence and health outcomes. Curr Opin Psychiatry. 2016 Mar;29(2):144–8. doi: 10.1097/yco.0000000000000229. X-126731557
6409 Wang L, Jia J, Zhang J, . Serum levels of sod and risk of autism spectrum disorder: A case-control study. International Journal of Developmental Neuroscience. 2016;51:12–6. doi: http://dx.doi.org/10.1016/j.ijdevneu.2016.04.004. X-127091401
6410 Wang L, Wee C-Y, Tang X, . Multi-task feature selection via supervised canonical graph matching for diagnosis of autism spectrum disorder. Brain Imaging and Behavior. 2016;10(1):33–40. doi: http://dx.doi.org/10.1007/s11682-015-9360-1. X-125761828
6411 Wang M, Spiegelman D, Kuchiba A, . Statistical methods for studying disease subtype heterogeneity. Stat Med. 2016 Feb 28;35(5):782–800. doi: 10.1002/sim.6793. X-126619806
6412 Wang Q, Hong P, Gao H, . An interneuron progenitor maintains neurogenic potential in vivo and differentiates into GABAergic interneurons after transplantation in the postnatal rat brain. Sci Rep. 2016;6:19003. doi: 10.1038/srep19003. X-126750620
6413 Wang W, Niu Z, Wang Y, . Comparative transcriptome analysis of atrial septal defect identifies dysregulated genes during heart septum morphogenesis. Gene. 2016 Jan 10;575(2 Pt 1):303–12. doi: 10.1016/j.gene.2015.09.016. X-126375510
6414 Wang X, Laffey J, Xing W, . Exploring embodied social presence of youth with Autism in 3D collaborative virtual learning environment: A case study. Computers in Human Behavior. 2016;51(Part A):310–21. doi: http://dx.doi.org/10.1016/j.chb.2015.09.006. X-1
6415 Wang Y, Billon C, Walker JK, . Therapeutic Effect of a Synthetic RORalpha/gamma Agonist in an Animal Model of Autism. ACS Chem Neurosci. 2016 Feb 17;7(2):143–8. doi: 10.1021/acschemneuro.5b00159. X-126625251
6416 Ward B, Tanner BS, Mandleco B, . Sibling Experiences: Living with Young Persons with Autism Spectrum Disorders. Pediatr Nurs. 2016 Mar–Apr;42(2):69–76. X-127254975
6417 Watanabe T, Rees G. Anatomical imbalance between cortical networks in autism. Sci Rep. 2016;6:31114. doi: 10.1038/srep31114. X-127484308
6418 Watson KJ, DiCarlo CF. Increasing completion of classroom routines through the use of picture activity schedules. Early Childhood Education Journal. 2016;44(2):89–96. doi: http://dx.doi.org/10.1007/s10643-015-0697-2. X-1, X-3, X-4
6419 Wauthia E, Rossignol M. Emotional processing and attention control impairments in children with anxiety: An integrative review of event-related potentials findings. Frontiers in Psychology. 2016;7. X-1
6420 Webb SJ, Neuhaus E, Faja S. Face perception and learning in autism spectrum disorders. Q J Exp Psychol (Hove). 2016 Mar 16:1–17. doi: 10.1080/17470218.2016.1151059. X-1
6421 Weber-Stadlbauer U, Richetto J, Labouesse MA, . Transgenerational transmission and modification of pathological traits induced by prenatal immune activation. Mol Psychiatry. 2016 Mar 29 doi: 10.1038/mp.2016.41. X-1
6422 Wee CY, Yap PT, Shen D. Diagnosis of autism spectrum disorders using temporally distinct resting-state functional connectivity networks. CNS Neuroscience & Therapeutics. 2016;22(3):212–9. doi: http://dx.doi.org/10.1111/cns.12499. X-126821773
6423 Wehman P, Schall CM, McDonough J, . Effects of an employer-based intervention on employment outcomes for youth with significant support needs due to autism. Autism. 2016 May 5 doi: 10.1177/1362361316635826. X-1
6424 Wei G, Deng X, Agarwal S, . Patient Mutations of the Intellectual Disability Gene KDM5C Downregulate Netrin G2 and Suppress Neurite Growth in Neuro2a Cells. J Mol Neurosci. 2016 Jul 16 doi: 10.1007/s12031-016-0770-3. X-1
6425 Wei H, Ma Y, Liu J, . Inhibition of IL-6 trans-signaling in the brain increases sociability in the BTBR mouse model of autism. Biochim Biophys Acta. 2016 Jul 25;1862(10):1918–25. doi: 10.1016/j.bbadis.2016.07.013. X-127460706
6426 Weiss JA, Ting V, Perry A. Psychosocial correlates of psychiatric diagnoses and maladaptive behaviour in youth with severe developmental disability. J Intellect Disabil Res. 2016 Jun;60(6):583–93. doi: 10.1111/jir.12278. X-127073035
6427 Weitzman C, Sia JH, Baroody OD, . Journal article reviews. Journal of Developmental and Behavioral Pediatrics. 2016;37(3):257–61. doi: http://dx.doi.org/10.1097/DBP.0000000000000275. X-1
6428 Welch CD, Polatajko HJ. Applied Behavior Analysis, Autism, and Occupational Therapy: A Search for Understanding. Am J Occup Ther. 2016 Jul–Aug;70(4):7004360020p1–5. doi: 10.5014/ajot.2016.018689. X-1, X-2
6429 Welles BF. Computational CAM: Studying children and media in the age of big data. Journal of Children and Media. 2016;10(1):72–80. doi: http://dx.doi.org/10.1080/17482798.2015.1123165. X-1
6430 Wells MF, Wimmer RD, Schmitt LI, . Thalamic reticular impairment underlies attention deficit in Ptchd1(Y/−) mice. Nature. 2016 Apr 7;532(7597):58–63. doi: 10.1038/nature17427. X-127007844
6431 Wells PG, Bhatia S, Drake DM, . Fetal oxidative stress mechanisms of neurodevelopmental deficits and exacerbation by ethanol and methamphetamine. Birth Defects Res C Embryo Today. 2016 Jun;108(2):108–30. doi: 10.1002/bdrc.21134. X-127345013
6432 Welsh JP, Oristaglio JT. Autism and Classical Eyeblink Conditioning: Performance Changes of the Conditioned Response Related to Autism Spectrum Disorder Diagnosis. Front Psychiatry. 2016;7:137. doi: 10.3389/fpsyt.2016.00137. X-127563293
6433 Wenger TL, Miller JS, DePolo LM, . 22q11.2 duplication syndrome: elevated rate of autism spectrum disorder and need for medical screening. Mol Autism. 2016;7:27. doi: 10.1186/s13229-016-0090-z. X-127158440
6434 Werling AM, Bobrowski E, Taurines R, . CNTNAP2 gene in high functioning autism: no association according to family and meta-analysis approaches. J Neural Transm (Vienna). 2016 Mar;123(3):353–63. doi: 10.1007/s00702-015-1458-5. X-126559825
6435 Werling DM, Parikshak NN, Geschwind DH. Gene expression in human brain implicates sexually dimorphic pathways in autism spectrum disorders. Nat Commun. 2016;7:10717. doi: 10.1038/ncomms10717. X-126892004
6436 Wernicke T, Kalbantner-Wernicke K. Fit for School: The Samurai School Program. Med Acupunct. 2016 Feb 1;28(1):33–9. doi: 10.1089/acu.2015.1147. X-1, X-2, X-326909127
6437 Wertz J, Zavos HMS, Matthews T, . Etiology of pervasive versus situational antisocial behaviors: A multi-informant longitudinal cohort study. Child Development. 2016;87(1):312–25. doi: http://dx.doi.org/10.1111/cdev.12456. X-126560743
6438 Westerveld MF, Trembath D, Shellshear L, . A systematic review of the literature on emergent literacy skills of preschool children with autism spectrum disorder. The Journal of Special Education. 2016;50(1):37–48. doi: http://dx.doi.org/10.1177/0022466915613593. X-1, X-2
6439 Whitaker L, Jones CRG, Wilkins AJ, . Judging the intensity of emotional expression in faces: The effects of colored tints on individuals with autism spectrum disorder. Autism Research. 2016;9(4):450–9. doi: http://dx.doi.org/10.1002/aur.1506. X-126058998
6440 White D, Hillier A, Frye A, . College Students’ Knowledge and Attitudes Towards Students on the Autism Spectrum. J Autism Dev Disord. 2016 May 26 doi: 10.1007/s10803-016-2818-1. X-1
6441 Wichnick-Gillis AM, Vener SM, Poulson CL. The effect of a script-fading procedure on social interactions among young children with autism. Research in Autism Spectrum Disorders. 2016;26:1–9. doi: http://dx.doi.org/10.1016/j.rasd.2016.03.004. X-3, X-4
6442 Wicker B, Monfardini E, Royet JP. Olfactory processing in adults with autism spectrum disorders. Mol Autism. 2016;7:4. doi: 10.1186/s13229-016-0070-3. X-126788281
6443 Wiener RC, Vohra R, Sambamoorthi U, . Caregiver Burdens and Preventive Dental Care for Children with Autism Spectrum Disorder, Developmental Disability and/or Mental Health Conditions: National Survey of CSHCN, 2009–2010. Matern Child Health J.. 2016 Jul 27 doi: 10.1007/s10995-016-2083-0. X-1
6444 Wilde L, Mitchell A, Oliver C. Differences in social motivation in children with Smith–Magenis syndrome and Down syndrome. Journal of Autism and Developmental Disorders. 2016;46(6):2148–59. doi: http://dx.doi.org/10.1007/s10803-016-2743-3. X-126983920
6445 Wilkes-Gillan S, Joosten A. Technology-based interventions were found to have evidence of effectiveness on a range of outcomes, including social problem solving and facial and emotional processing skills for individuals with autism spectrum disorders. Aust Occup Ther J. 2016 Apr;63(2):135–6. doi: 10.1111/1440-1630.12274. X-1, X-2, X-3, X-427045530
6446 Wilkinson M, Wang R, van der Kouwe A, . White and gray matter fiber pathways in autism spectrum disorder revealed by ex vivo diffusion MR tractography. Brain Behav. 2016 May 5:e00483. doi: 10.1002/brb3.483. X-1
6447 Williams KE, Sciberras E. Sleep and self-regulation from birth to 7 years: A retrospective study of children with and without attention-deficit hyperactivity disorder at 8 to 9 years. Journal of Developmental and Behavioral Pediatrics. 2016;37(5):385–94. doi: http://dx.doi.org/10.1097/DBP.0000000000000281. X-126982247
6448 Williamson AA, Patrick KE, Rubens SL, . Pediatric sleep disorders in an outpatient sleep clinic: Clinical presentation and needs of children with neurodevelopmental conditions. Clinical Practice in Pediatric Psychology. 2016;4(2):188–99. doi: http://dx.doi.org/10.1037/cpp0000135. X-1
6449 Willis K, Timmons L, Pruitt M, . The Relationship Between Optimism, Coping, and Depressive Symptoms in Hispanic Mothers and Fathers of Children with Autism Spectrum Disorder. J Autism Dev Disord. 2016 Jul;46(7):2427–40. doi: 10.1007/s10803-016-2776-7. X-127017210
6450 Wilmot B, Fry R, Smeester L, . Methylomic analysis of salivary DNA in childhood ADHD identifies altered DNA methylation in VIPR2. Journal of Child Psychology and Psychiatry. 2016;57(2):152–60. doi: http://dx.doi.org/10.1111/jcpp.12457. X-126304033
6451 Wilson CE, Murphy CM, McAlonan G, . Does sex influence the diagnostic evaluation of autism spectrum disorder in adults? Autism. 2016 Jan 22 doi: 10.1177/1362361315611381. X-1
6452 Wilson TW, Heinrichs-Graham E, Proskovec AL, . Neuroimaging with magnetoencephalography: A dynamic view of brain pathophysiology. Transl Res. 2016 Jan 25 doi: 10.1016/j.trsl.2016.01.007. X-1
6453 Wise T, Radua J, Via E, . Common and distinct patterns of grey-matter volume alteration in major depression and bipolar disorder: evidence from voxel-based meta-analysis. Mol Psychiatry. 2016 May 24 doi: 10.1038/mp.2016.72. X-1
6454 Witteveen JS, Willemsen MH, Dombroski TC, . Haploinsufficiency of MeCP2-interacting transcriptional co-repressor SIN3A causes mild intellectual disability by affecting the development of cortical integrity. Nat Genet. 2016 Aug;48(8):877–87. doi: 10.1038/ng.3619. X-127399968
6455 Wodka EL, Puts NA, Mahone EM, . The Role of Attention in Somatosensory Processing: A Multi-trait, Multi-method Analysis. J Autism Dev Disord. 2016 Jul 22 doi: 10.1007/s10803-016-2866-6. X-1
6456 Wolff N, Rubia K, Knopf H, . Reduced pain perception in children and adolescents with ADHD is normalized by methylphenidate. Child and Adolescent Psychiatry and Mental Health. 2016;10. X-1, X-427200107
6457 Wong CM, Koh HC. Brief Report: Investigating the Implications of Applying the New DSM-5 Criteria for Diagnosing Autism Spectrum Disorder in a Preschool Population in Singapore. J Autism Dev Disord. 2016 Jun 18 doi: 10.1007/s10803-016-2841-2. X-1
6458 Wong S, Giulivi C. Autism, Mitochondria and Polybrominated Diphenyl Ether Exposure. CNS Neurol Disord Drug Targets. 2016;15(5):614–23. X-127071785
6459 Woodman AC, Smith LE, Greenberg JS, . Contextual Factors Predict Patterns of Change in Functioning over 10 Years Among Adolescents and Adults with Autism Spectrum Disorders. J Autism Dev Disord. 2016 Jan;46(1):176–89. doi: 10.1007/s10803-015-2561-z. X-126319253
6460 Worth AJ, Marchione DM, Parry RC, . LC-MS Analysis of Human Platelets as a Platform for Studying Mitochondrial Metabolism. J Vis Exp. 2016(110):e53941. doi: 10.3791/53941. X-127077278
6461 Woynaroski T, Watson L, Gardner E, . Early predictors of growth in diversity of key consonants used in communication in initially preverbal children with autism spectrum disorder. Journal of Autism and Developmental Disorders. 2016;46(3):1013–24. doi: http://dx.doi.org/10.1007/s10803-015-2647-7. X-126603885
6462 Wright HF, Hall S, Mills DS. Additional evidence is needed to recommend acquiring a dog to families of children with Autism Spectrum Disorder: A response to Crossman and Kazdin. Journal of Autism and Developmental Disorders. 2016;46(1):336–9. doi: http://dx.doi.org/10.1007/s10803-015-2548-9. X-126340955
6463 Wright K, Kelley E, Poulin-Dubois D. Biological motion and the animate–inanimate distinction in children with high-functioning Autism Spectrum Disorder. Research in Autism Spectrum Disorders. 2016;25:1–11. doi: http://dx.doi.org/10.1016/j.rasd.2016.01.005. X-1
6464 Wu YE, Parikshak NN, Belgard TG, . Genome-wide, integrative analysis implicates microRNA dysregulation in autism spectrum disorder. Nat Neurosci. 2016 Aug 29 doi: 10.1038/nn.4373. X-1
6465 Wu Y-T, Maenner MJ, Wiggins LD, . Retention of autism spectrum disorder diagnosis: The role of co-occurring conditions in males and females. Research in Autism Spectrum Disorders. 2016;25:76–86. doi: http://dx.doi.org/10.1016/j.rasd.2016.02.001. X-1
6466 Xavier A, Pinto Gouveia J, Cunha M. Non-suicidal self-injury in adolescence: The role of shame, self-criticism and fear of self-compassion. Child & Youth Care Forum. 2016;45(4):571–86. doi: http://dx.doi.org/10.1007/s10566-016-9346-1. X-1
6467 Xie P, Zang LQ, Li XK, . An epigenetic view of developmental diseases: new targets, new therapies. World J Pediatr. 2016 Aug;12(3):291–7. doi: 10.1007/s12519-016-0020-3. X-127351564
6468 Xie Z, Li J, Baker J, . Receptor Tyrosine Kinase MET Interactome and Neurodevelopmental Disorder Partners at the Developing Synapse. Biol Psychiatry. 2016 Feb 26 doi: 10.1016/j.biopsych.2016.02.022. X-1
6469 Xu L, Mitchell LC, Richman AR, . What Do Parents Think about Chromosomal Microarray Testing? A Qualitative Report from Parents of Children with Autism Spectrum Disorders. Autism Res Treat. 2016;2016:6852539. doi: 10.1155/2016/6852539. X-127413549
6470 Xu Q, Goldstein J, Wang P,. Chromosomal microarray analysis in clinical evaluation of neurodevelopmental disorders-reporting a novel deletion of SETDB1 and illustration of counseling challenge. Pediatr Res. 2016 Jun 1 doi: 10.1038/pr.2016.101. X-1
6471 Xu Z, Jiang H, Zhong P, . Direct conversion of human fibroblasts to induced serotonergic neurons. Mol Psychiatry. 2016 Jan;21(1):62–70. doi: 10.1038/mp.2015.101. X-126216300
6472 Yaari M, Yitzhak N, Harel A, . Stability of early risk assessment for autism spectrum disorder in preterm infants. Autism. 2016 Jan 22 doi: 10.1177/1362361315614758. X-1
6473 Yagi M, Ohne H, Konomi T, . Teriparatide improves volumetric bone mineral density and fine bone structure in the UIV+1 vertebra, and reduces bone failure type PJK after surgery for adult spinal deformity. Osteoporos Int. 2016 Jun 24 doi: 10.1007/s00198-016-3676-6. X-1
6474 Yakubova G, Hughes EM, Shinaberry M. Learning with Technology: Video Modeling with Concrete-Representational-Abstract Sequencing for Students with Autism Spectrum Disorder. J Autism Dev Disord. 2016 Jul;46(7):2349–62. doi: 10.1007/s10803-016-2768-7. X-1, X-3, X-426983919
6475 Yakubova G, Hughes EM, Shinaberry M. Learning with technology: Video modeling with concrete–representational–abstract sequencing for students with autism spectrum disorder. Journal of Autism and Developmental Disorders. 2016;46(7):2349–62. doi: http://dx.doi.org/10.1007/s10803-016-2768-7. X-3, X-426983919
6476 Yalcin O, Kaymak G, Erdogan A, . A Retrospective Investigation of Clozapine Treatment in Autistic and Nonautistic Children and Adolescents in an Inpatient Clinic in Turkey. J Child Adolesc Psychopharmacol. 2016 Jan 15 doi: 10.1089/cap.2015.0020. X-1, X-3
6477 Yamasaki K, Hoshino M, Omori K, . Risk Factors of Adjacent Segment Disease after Transforaminal Inter-Body Fusion for Degenerative Lumbar Disease. Spine (Phila Pa 1976). 2016 Jun 6 doi: 10.1097/brs.0000000000001728. X-1
6478 Yamasaki M, Miyagawa T, Toyoda H, . Evaluation of polygenic risks for narcolepsy and essential hypersomnia. J Hum Genet. 2016 Jun 16 doi: 10.1038/jhg.2016.65. X-1
6479 Yamasaki Y, Nagao M, Kawanami S, . One-stop shop assessment for atrial septal defect closure using 256-slice coronary CT angiography. Eur Radiol. 2016 May 28 doi: 10.1007/s00330-016-4407-2. X-1
6480 Yang DY, Beam D, Pelphrey KA, . Cortical morphological markers in children with autism: a structural magnetic resonance imaging study of thickness, area, volume, and gyrification. Mol Autism. 2016;7:11. doi: 10.1186/s13229-016-0076-x. X-126816612
6481 Yang EJ, Ahn S, Lee K, . Correction: Early Behavioral Abnormalities and Perinatal Alterations of PTEN/AKT Pathway in Valproic Acid Autism Model Mice. PLoS One. 2016;11(6):e0157202. doi: 10.1371/journal.pone.0157202. X-127258156
6482 Yang S, Paynter JM, Gilmore L. Vineland Adaptive Behavior Scales: II profile of young children with autism spectrum disorder. Journal of Autism and Developmental Disorders. 2016;46(1):64–73. doi: http://dx.doi.org/10.1007/s10803-015-2543-1. X-126231205
6483 Yang X, Meng X. Dissociation between exact and approximate addition in developmental dyslexia. Research in Developmental Disabilities. 2016;56:139–52. doi: http://dx.doi.org/10.1016/j.ridd.2016.05.018. X-127310366
6484 Yang X, Si T, Gong Q, . Brain gray matter alterations and associated demographic profiles in adults with autism spectrum disorder: A meta-analysis of voxel-based morphometry studies. Aust N Z J Psychiatry. 2016 Jan 14 doi: 10.1177/0004867415623858. X-1
6485 Yang Y, Zhang W, Wu Q, . Transcatheter closure of atrial septal defects without fluoroscopy: a well-established procedure for alternative use in children. EuroIntervention. 2016;12(5):e652–7. doi: 10.4244/eijv12i5a106. X-127497366
6486 Yang YH. Parents and Young Children with Disabilities: The Effects of a Home-Based Music Therapy Program on Parent-Child Interactions. J Music Ther. 2016 Spring;53(1):27–54. doi: 10.1093/jmt/thv018. X-326647404
6487 Yang Z, Ren Y, Liu D, . Prevalence of systemic autoimmune rheumatic diseases and clinical significance of ANA profile: data from a tertiary hospital in Shanghai, China. Apmis. 2016 Jun 22 doi: 10.1111/apm.12564. X-1
6488 Yau SH, Brock J, McArthur G. The relationship between spoken language and speech and nonspeech processing in children with autism: a magnetic event-related field study. Dev Sci. 2016 May 4 doi: 10.1111/desc.12328. X-1
6489 Yeetong P, Vilboux T, Ciccone C, . Delayed diagnosis in a house of correction: Smith-Magenis syndrome due to a de novo nonsense RAI1 variant. Am J Med Genet A. 2016 Jun 17 doi: 10.1002/ajmg.a.37602. X-1
6490 Yen CP, Mosley YI, Uribe JS. Role of minimally invasive surgery for adult spinal deformity in preventing complications. Curr Rev Musculoskelet Med. 2016 Sep;9(3):309–15. doi: 10.1007/s12178-016-9355-6. X-127411527
6491 Yeramaneni S, Robinson C, Hostin R. Impact of spine surgery complications on costs associated with management of adult spinal deformity. Curr Rev Musculoskelet Med. 2016 Jun 9 doi: 10.1007/s12178-016-9352-9. X-1
6492 Yi F, Danko T, Botelho SC, . Autism-associated SHANK3 haploinsufficiency causes Ih channelopathy in human neurons. Science. 2016 6;352(6286):aaf2669. doi: 10.1126/science.aaf2669. X-126966193
6493 Yi L, Quinn PC, Fan Y, . Children with Autism Spectrum Disorder scan own-race faces differently from other-race faces. Journal of Experimental Child Psychology. 2016;141:177–86. doi: http://dx.doi.org/10.1016/j.jecp.2015.09.011. X-126435179
6494 Yildiz A, Tarakci D, Hajebrahimi F, . Disabled children’s functionality and their mother’s Quality of life and psychological status. Pediatr Int. 2016 Apr 16 doi: 10.1111/ped.13020. X-1
6495 Yimgang DP, Albury RA, Leppert ML. Do Parental Concerns Predict Developmental and Behavioral Diagnoses in a Developmental Clinic? Clin Pediatr (Phila). 2016 May 19 doi: 10.1177/0009922816648289. X-1
6496 Yitzhak N, Harel A, Yaari M, . The Mullen scales of early learning: Ceiling effects among preschool children. European Journal of Developmental Psychology. 2016;13(1):138–51. doi: http://dx.doi.org/10.1080/17405629.2015.1073584. X-1
6497 Yochum A. Autism Spectrum/Pervasive Developmental Disorder. Prim Care. 2016 Jun;43(2):285–300. doi: 10.1016/j.pop.2016.01.010. X-127262008
6498 Yoo MH, Kim TY, Yoon YH, . Autism phenotypes in ZnT3 null mice: Involvement of zinc dyshomeostasis, MMP-9 activation and BDNF upregulation. Sci Rep. 2016;6:28548. doi: 10.1038/srep28548. X-127352957
6499 Yoon Y, Wink LK, Pedapati EV, . Weight Gain Effects of Second-Generation Antipsychotic Treatment in Autism Spectrum Disorder. J Child Adolesc Psychopharmacol. 2016 Jul 7 doi: 10.1089/cap.2016.0049. X-1, X-3
6500 Yoshida G, Boissiere L, Larrieu D, . Advantages and Disadvantages of Adult Spinal Deformity Surgery and its Impact on Health-related Quality of Life. Spine (Phila Pa 1976). 2016 Jul 7 doi: 10.1097/brs.0000000000001770. X-1
6501 Yoshimura Y, Kikuchi M, Hiraishi H, . Atypical development of the central auditory system in young children with Autism spectrum disorder. Autism Res. 2016 Jan 25 doi: 10.1002/aur.1604. X-1
6502 Young AM, Chakrabarti B, Roberts D, . From molecules to neural morphology: understanding neuroinflammation in autism spectrum condition. Mol Autism. 2016;7:9. doi: 10.1186/s13229-016-0068-x. X-126793298
6503 Young N, Hudry K, Trembath D, . Children With Autism Show Reduced Information Seeking When Learning New Tasks. Am J Intellect Dev Disabil. 2016 Jan;121(1):65–73. doi: 10.1352/1944-7558-121.1.65. X-126701075
6504 Young RL, Nah YH. Examining autism detection in early childhood (ADEC) in the early identification of young children with autism spectrum disorders (ASD). Australian Psychologist. 2016;51(4):261–71. doi: http://dx.doi.org/10.1111/ap.12223. X-1
6505 Yu B. Bilingualism as conceptualized and bilingualism as lived: A critical examination of the monolingual socialization of a child with autism in a bilingual family. Journal of Autism and Developmental Disorders. 2016;46(2):424–35. doi: http://dx.doi.org/10.1007/s10803-015-2625-0. X-126519327
6506 Yu H, Liu J, Yang A, . Lack of association between polymorphisms in dopa decarboxylase and dopamine receptor-1 genes with childhood autism in Chinese Han population. Journal of Child Neurology. 2016;31(5):560–4. doi: http://dx.doi.org/10.1177/0883073815601496. X-126337060
6507 Yuan X, Devine DP. The role of anxiety in vulnerability for self-injurious behaviour: studies in a rodent model. Behav Brain Res. 2016 Sep 15;311:201–9. doi: 10.1016/j.bbr.2016.05.041. X-127217100
6508 Yui K, Imataka G, Kawasak Y, . Increased omega-3 polyunsaturated fatty acid/arachidonic acid ratios and upregulation of signaling mediator in individuals with autism spectrum disorders. Life Sci. 2016 Jan 15;145:205–12. doi: 10.1016/j.lfs.2015.12.039. X-126724495
6509 Yui K, Imataka G, Kawasaki Y, . Down-regulation of a signaling mediator in association with lowered plasma arachidonic acid levels in individuals with autism spectrum disorders. Neurosci Lett. 2016 Jan 1;610:223–8. doi: 10.1016/j.neulet.2015.11.006. X-126552013
6510 Yun S-S, Kim H, Choi J, . A robot-assisted behavioral intervention system for children with autism spectrum disorders. Robotics and Autonomous Systems. 2016;76:58–67. doi: http://dx.doi.org/10.1016/j.robot.2015.11.004. X-1
6511 Zahorakova D, Lelkova P, Gregor V, . MECP2 mutations in Czech patients with Rett syndrome and Rett-like phenotypes: novel mutations, genotype-phenotype correlations and validation of high-resolution melting analysis for mutation scanning. J Hum Genet. 2016 Mar 17 doi: 10.1038/jhg.2016.19. X-1
6512 Zaidman-Zait A, Curle D. Complexity: An interpretative phenomenological analysis of the experiences of mothers of deaf children with cochlear implants and autism. J Health Psychol. 2016 May 16 doi: 10.1177/1359105316646171. X-1
6513 Zaidman-Zait A, Mirenda P, Duku E, . Impact of personal and social resources on parenting stress in mothers of children with autism spectrum disorder. Autism. 2016 Apr 18 doi: 10.1177/1362361316633033. X-1
6514 Zainal H, Magiati I. A Comparison Between Caregiver-Reported Anxiety and Other Emotional and Behavioral Difficulties in Children and Adolescents with Autism Spectrum Disorders Attending Specialist or Mainstream Schools. J Autism Dev Disord. 2016 May 10 doi: 10.1007/s10803-016-2792-7. X-1
6515 Zamponi GW. Targeting voltage-gated calcium channels in neurological and psychiatric diseases. Nat Rev Drug Discov. 2016 Jan;15(1):19–34. doi: 10.1038/nrd.2015.5. X-1, X-2, X-3, X-426542451
6516 Zanatta G, Della Flora Nunes G, Bezerra EM, . Two Binding Geometries for Risperidone in Dopamine D3 Receptors: Insights on the Fast-Off Mechanism through Docking, Quantum Biochemistry, and Molecular Dynamics Simulations. ACS Chem Neurosci.. 2016 Aug 5 doi: 10.1021/acschemneuro.6b00074. X-1
6517 Zander E, Willfors C, Berggren S, . The objectivity of the Autism Diagnostic Observation Schedule (ADOS) in naturalistic clinical settings. European Child & Adolescent Psychiatry. 2016;25(7):769–80. doi: http://dx.doi.org/10.1007/s00787-015-0793-2. X-126584575
6518 Zarafshan H, Khaleghi A, Mohammadi MR, . Electroencephalogram complexity analysis in children with attention-deficit/hyperactivity disorder during a visual cognitive task. Journal of Clinical and Experimental Neuropsychology. 2016;38(3):361–9. doi: http://dx.doi.org/10.1080/13803395.2015.1119252. X-126678277
6519 Zauche LH, Thul TA, Mahoney AED, . Influence of language nutrition on children’s language and cognitive development: An integrated review. Early Childhood Research Quarterly. 2016;36:318–33. doi: http://dx.doi.org/10.1016/j.ecresq.2016.01.015. X-1
6520 Zavadenko NN, Suvorinova NY. Results of pharmacotherapy of attention deficit hyperactivity disorder: Assessment using neuropsychological methods. Neuroscience and Behavioral Physiology. 2016;46(3):354–9. doi: http://dx.doi.org/10.1007/s11055-016-0241-x. X-1
6521 Zeedyk SM, Cohen SR, Eisenhower A, . Perceived social competence and loneliness among young children with ASD: Child, parent and teacher reports. Journal of Autism and Developmental Disorders. 2016;46(2):436–49. doi: http://dx.doi.org/10.1007/s10803-015-2575-6. X-126363914
6522 Zeidan-Chulia F, de Oliveira BH, Casanova MF, . Up-Regulation of Oligodendrocyte Lineage Markers in the Cerebellum of Autistic Patients: Evidence from Network Analysis of Gene Expression. Mol Neurobiol. 2016 Aug;53(6):4019–25. doi: 10.1007/s12035-015-9351-7. X-126189831
6523 Zerbo O, Traglia M, Yoshida C, . Maternal mid-pregnancy C-reactive protein and risk of autism spectrum disorders: the early markers for autism study. Transl Psychiatry. 2016;6:e783. doi: 10.1038/tp.2016.46. X-127093065
6524 Zettergren A, Karlsson S, Hovey D, . Further investigations of the relation between polymorphisms in sex steroid related genes and autistic-like traits. Psychoneuroendocrinology. 2016;68:1–5. doi: http://dx.doi.org/10.1016/j.psyneuen.2016.02.020. X-126930261
6525 Zhang B, Zou J, Han L, . Microglial activation during epileptogenesis in a mouse model of tuberous sclerosis complex. Epilepsia. 2016 Jun 6 doi: 10.1111/epi.13429. X-1
6526 Zhang D, Cui H, Zhang L, . Is maternal smoking during pregnancy associated with an increased risk of congenital heart defects among offspring? A systematic review and meta-analysis of observational studies. J Matern Fetal Neonatal Med. 2016 May 16:1–13. doi: 10.1080/14767058.2016.1183640. X-1
6527 Zhang H, Harris L, Split M, . Anhedonia and individual differences in orbitofrontal cortex sulcogyral morphology. Hum Brain Mapp. 2016 Jun 22 doi: 10.1002/hbm.23282. X-1
6528 Zhang HF, Dai YC, Wu J, . Plasma Oxytocin and Arginine-Vasopressin Levels in Children with Autism Spectrum Disorder in China: Associations with Symptoms. Neurosci Bull. 2016 Jun 24 doi: 10.1007/s12264-016-0046-5. X-1
6529 Zhang J, Cheng W, Liu Z, . Neural, electrophysiological and anatomical basis of brain-network variability and its characteristic changes in mental disorders. Brain. 2016 Aug;139(Pt 8):2307–21. doi: 10.1093/brain/aww143. X-127421791
6530 Zhang J, Zhang JX, Zhang QL. PI3K/AKT/mTOR-mediated autophagy in the development of autism spectrum disorder. Brain Res Bull. 2016 Jun 16 doi: 10.1016/j.brainresbull.2016.06.007. X-1
6531 Zhang T, Shao Z, Zhang Y. Developmental steps in theory of mind of typical Chinese children and Chinese children with autism spectrum disorder. Research in Autism Spectrum Disorders. 2016;23:210–20. doi: http://dx.doi.org/10.1016/j.rasd.2015.10.005. X-1
6532 Zhang W, Baranek G. The Impact of Insurance Coverage Types on Access to and Utilization of Health Services for U.S Children With Autism Psychiatr Serv. 2016 Apr 15:appips201500206. doi: 10.1176/appi.ps.201500206. X-1
6533 Zhang Y, Chen M, Qiu Z, . MiR-130a regulates neurite outgrowth and dendritic spine density by targeting MeCP2. Protein Cell. 2016 Jul;7(7):489–500. doi: 10.1007/s13238-016-0272-7. X-127245166
6534 Zhang Y, Hodgson NW, Trivedi MS, . Decreased Brain Levels of Vitamin B12 in Aging, Autism and Schizophrenia. PLoS One. 2016;11(1):e0146797. doi: 10.1371/journal.pone.0146797. X-126799654
6535 Zhang Y, Shan JL, Liu XM, . Comparison of the Dynesys Dynamic Stabilization System and Posterior Lumbar Interbody Fusion for Lumbar Degenerative Disease. PLoS One. 2016;11(1):e0148071. doi: 10.1371/journal.pone.0148071. X-126824851
6536 Zhao F, Qiao L, Shi F, . Feature fusion via hierarchical supervised local CCA for diagnosis of autism spectrum disorder. Brain Imaging Behav. 2016 Aug 17 doi: 10.1007/s11682-016-9587-5. X-1
6537 Zhao Y, Castellanos FX. Annual research review: Discovery science strategies in studies of the pathophysiology of child and adolescent psychiatric disorders—Promises and limitations. Journal of Child Psychology and Psychiatry. 2016;57(3):421–39. doi: http://dx.doi.org/10.1111/jcpp.12503. X-126732133
6538 Zhao Y, Chen H, Li Y, . Connectome-scale group-wise consistent resting-state network analysis in autism spectrum disorder. Neuroimage Clin. 2016;12:23–33. doi: 10.1016/j.nicl.2016.06.004. X-127358766
6539 Zhong J, Amina S, Liang M, . Cyclic ADP-Ribose and Heat Regulate Oxytocin Release via CD38 and TRPM2 in the Hypothalamus during Social or Psychological Stress in Mice. Front Neurosci. 2016;10:304. doi: 10.3389/fnins.2016.00304. X-127499729
6540 Zhou J, Zhang X, Ren J, . Validation of reference genes for quantitative real-time PCR in valproic acid rat models of autism. Mol Biol Rep. 2016 Jun 10 doi: 10.1007/s11033-016-4015-x. X-1
6541 Zhou P, Zhang Y, Wei C, . Acute stress disorder as a predictor of posttraumatic stress: A longitudinal study of Chinese children exposed to the Lushan earthquake. Psych J. 2016 Jun 22 doi: 10.1002/pchj.136. X-1
6542 Zhou Y, Kaiser T, Monteiro P, . Mice with Shank3 Mutations Associated with ASD and Schizophrenia Display Both Shared and Distinct Defects. Neuron. 2016 Jan 6;89(1):147–62. doi: 10.1016/j.neuron.2015.11.023. X-126687841
6543 Zhu Y, Xing B, Dang W, . AUTS2 in the nucleus accumbens is essential for heroin-induced behavioral sensitization. Neuroscience. 2016 Jul 14;333:35–43. doi: 10.1016/j.neuroscience.2016.07.007. X-127423627
6544 Zhu Y, Zhang B, Liu H, . Cervical Disc Arthroplasty Versus Anterior Cervical Discectomy and Fusion for Incidence of Symptomatic Adjacent Segment Disease: A Meta-Analysis of Prospective Randomized Controlled Trials. Spine (Phila Pa 1976). 2016 Feb 26 doi: 10.1097/brs.0000000000001537. X-1
6545 Ziats MN, Goin-Kochel RP, Berry LN, . The complex behavioral phenotype of 15q13.3 microdeletion syndrome. Genet Med. 2016 Mar 10 doi: 10.1038/gim.2016.9. X-1
6546 Ziegler A, Neues F, Janacek J, . Mineral in skeletal elements of the terrestrial crustacean Porcellio scaber: SRmuCT of function related distribution and changes during the moult cycle. Arthropod Struct Dev. 2016 Jun 30 doi: 10.1016/j.asd.2016.05.004. X-1
6547 Zilkha N, Kuperman Y, Kimchi T. High-fat diet exacerbates cognitive rigidity and social deficiency in the BTBR mouse model of autism. Neuroscience. 2016 Feb 11 doi: 10.1016/j.neuroscience.2016.01.070. X-1
6548 Zimmermann FF, Gaspary KV, Siebel AM, . Oxytocin reversed MK-801-induced social interaction and aggression deficits in zebrafish. Behav Brain Res. 2016 Sep 15;311:368–74. doi: 10.1016/j.bbr.2016.05.059. X-127247142
6549 Zimmermann FF, Gaspary KV, Siebel AM, . Analysis of Extracellular Nucleotide Metabolism in Adult Zebrafish After Embryological Exposure to Valproic Acid. Mol Neurobiol. 2016 May 17 doi: 10.1007/s12035-016-9917-z. X-1
6550 Zink AG, Diniz MB, Rodrigues Dos Santos MT, . Use of a Picture Exchange Communication System for preventive procedures in individuals with autism spectrum disorder: pilot study. Spec Care Dentist. 2016 Apr 5 doi: 10.1111/scd.12183. X-1
6551 Zohar AH, Dahan D. Young children’s ritualistic compulsive-like behavior and executive function: A cross sectional study. Child Psychiatry and Human Development. 2016;47(1):13–22. doi: http://dx.doi.org/10.1007/s10578-015-0539-x. X-125725602
6552 Zuckerman K, Lindly OJ, Chavez AE. Timeliness of Autism Spectrum Disorder Diagnosis and Use of Services Among U.S. Elementary School-Aged Children. Psychiatr Serv. 2016 Aug 1:appips201500549. doi: 10.1176/appi.ps.201500549. X-1
6553 Zuko A, Oguro-Ando A, van Dijk R, . Developmental role of the cell adhesion molecule Contactin-6 in the cerebral cortex and hippocampus. Cell Adh Migr. 2016 Mar 3:1–15. doi: 10.1080/19336918.2016.1155018. X-1
6554 Zwaigenbaum L, Bryson SE, Brian J, . Stability of diagnostic assessment for autism spectrum disorder between 18 and 36 months in a high-risk cohort. Autism Research. 2016;9(7):790–800. doi: http://dx.doi.org/10.1002/aur.1585. X-126613202
6555 Zwanenburg RJ, Bocca G, Ruiter SA, . Is there an effect of intranasal insulin on development and behaviour in Phelan-McDermid syndrome? A randomized, double-blind, placebo-controlled trial. Eur J Hum Genet. 2016 Aug 31 doi: 10.1038/ejhg.2016.109. X-1
6556 Zwanenburg RJ, Ruiter SAJ, van den Heuvel ER, . Developmental phenotype in Phelan-McDermid (22q13.3 deletion) syndrome: A systematic and prospective study in 34 children. Journal of Neurodevelopmental Disorders. 2016;8 doi: http://dx.doi.org/10.1186/s11689-016-9150-0. X-126981159