# Appendix C Screening and Quality Assessment Forms

Medical and Sensory-Related Therapies for Children with Autism Spectrum Disorder Abstract Review Form

Medical and Sensory-Related Therapies for Children with Autism Spectrum Disorder Full Text Review Form

Medical and Sensory-Related Therapies for Children with Autism Spectrum Disorder Risk of Bias Form