# Appendix B Search Strategies

Table B-1 Treatment/intervention

Interface: PubMed; Database: Medline

| Search | Records
1 | “Child Development Disorders, Pervasive”[Mesh] | 22690
2 | (autistic[tiab] OR autism[tiab] OR asperger[tiab] OR asperger’s[tiab] OR aspergers[tiab] OR pervasive development[tiab] OR pervasive developmental[tiab] OR pdd[tiab]) NOT medline[sb] | 5613
3 | #1 OR #2 | 28303
4 | therapy[sh] OR therapeutics[mh] OR psychotherapy[mh] OR treatment outcome[mh] | 7271756
5 | (treatment[tiab] OR therapy[tiab] OR intervention[tiab] OR “control group”[tiab] OR randomized[tiab] OR outcome[tiab] OR randomized[tiab] OR efficacy[tiab] OR effectiveness[tiab] OR comparison[tiab] OR compared[tiab] OR trial[tiab] OR “pilot study”[tiab] ) NOT medline[sb] | 794459
6 | #4 OR #5 | 8058741
7 | #3 AND #6 | 9859
8 | (newspaper article[pt] OR comment[pt] OR case reports[pt] OR review[pt] OR practice guideline[pt] OR news[pt] OR editorial[pt] OR historical article[pt] OR meta-analysis[pt] OR legal cases[pt] OR published erratum[pt] OR congresses[pt]) | 5128288
9 | #7 NOT #8 | 6801
10 | #9 limited to (“2010/01/01”[Date - Publication] : “3000”[Date - Publication]) | 3894

Key: [mh] Medical Subject Heading; [tiab] title/abstract word; [pt] publication type; [sh] subheading; [dp] publication date; [la] language; [pt] publication type.

Table B-2 Sensory integration search in CINAHL

Interface: EBSCO host; Database: CINAHL

| Search | Records
1 | (MH “Autistic Disorder”) | 10,856
2 | (MH “Child Development Disorders”) OR (MH “Child Development Disorders, Pervasive”) | 2,067
3 | “autism” | 8,856
4 | #2 AND #3 | 511
5 | #1 OR #4 | 11,134
6 | (MH “Sensory Motor Integration”) OR (MH “Psychomotor Performance+”) OR (MH “Motor Skills+”) | 15,630
7 | (MH “Occupational Therapy”) OR (MH “Pediatric Occupational Therapy”) | 15,278
8 | sensory | 12,670
9 | #7 AND #8 | 512
10 | #6 OR #9 | 15,853
11 | #5 AND #10 | 461
12 | #11 limited to 2010–2015 | 263
13 | #12 limited to English language | 262

Table B-3 Sensory integration search in PsycInfo

Database: PsycInfo

Search | Records
SU.EXACT.EXPLODE(“Sensory Integration”) AND SU.EXACT.EXPLODE(“Autism”) Limited to 2010–2015 | 39