# Appendix A Detailed Methods

## Topic Surveillance and Review Protocol

These procedures follow the methods outlined in the Agency for Healthcare Research and Quality (AHRQ) Effective Health Care Program Methods Guide for Effectiveness and Comparative Effectiveness Reviews.^1^ The topic for the original report^2^ was nominated by Autism Speaks in a public process using the Effective Health Care website. AHRQ published an update addressing behavioral interventions in 2014.^3^ We conducted a surveillance process to assess the need to update the report by contacting topic experts about the relevance of the Key Questions (KQs) and new evidence that may address them. All members of the research team were required to submit information about potential conflicts of interest before initiation of the work. No members of the review team had any conflicts.

In consultation with clinical experts and stakeholders, and based on our preliminary scan of the literature and surveillance findings, we focused the review update on approaches to address sensory challenges and medical approaches (reported in a separate update). These areas reflect both areas of clinical relevance and sufficient newly published literature for a review update. Given the different foci of these interventions (i.e., sensory challenges and challenging behaviors) and subsequent differences in study populations, we report findings in two separate reviews.

Based also on the surveillance process and discussions with stakeholders, we revised the KQ addressed in the 2011 report to reflect the focus on medical and sensory approaches specifically. We also eliminated a question on approaches for children at risk for ASD as such children are unlikely to be included in studies in the target areas for this review update.

After review from AHRQ, the questions and framework were posted online for public comment. No changes to the questions or framework were recommended. We identified technical experts on the topic to provide assistance during the project. The Technical Expert Panel (TEP), representing the fields of pediatrics and developmental pediatrics, psychiatry, family medicine, and occupational therapy and allied health, contributed to the AHRQ’s broader goals of (1) creating and maintaining science partnerships as well as public-private partnerships and (2) meeting the needs of an array of potential users of its products. Thus, the TEP was both an additional resource and a sounding board during the project. The TEP included seven members serving as technical or clinical experts. To ensure robust, scientifically relevant work, TEP members participated in conference calls to:

- Help to refine the analytic framework and KQ at the beginning of the project;
- Discuss inclusion/exclusion criteria; and
- Assist with determining key interventions and outcomes of interest.

The final protocol was posted to the AHRQ Effective Health Care web site and registered in the PROSPERO international register of systematic reviews (ID#: CRD42016033941).

## Literature Search Strategy

### Search Strategy

To ensure comprehensive retrieval of relevant studies of therapies for children with ASD, we used four key databases: the MEDLINE^®^ medical literature database via the PubMed^®^ interface; EMBASE (Excerpta Medica Database), an international biomedical and pharmacological literature database via the Ovid^®^ interface; the Cumulative Index of Nursing and Allied Health Literature (CINAHL), and PsycINFO^®^. Search strategies for KQs applied a combination of controlled vocabulary (Medical Subject Headings [MeSH] and Emtree headings) to focus specifically on interventions targeting sensory challenges in children with ASD and harms of interventions (Appendix B). We restricted literature searches for KQs to studies published from 2010 to September 2016 to reflect literature available since the publication of the 2011 review. We will update searches while the report is undergoing peer review.

#### Gray Literature

We searched web sites of organizations likely to conduct research, issue guidance, or generate policies for ASD (e.g., Autism Speaks, the American Academy of Child and Adolescent Psychiatry) to inform the review’s background and discussion sections. We searched government and regulatory agency web sites for contextual information on benefits and harms of ASD interventions. We searched ClinicalTrials.gov and other trial registries for information about relevant ongoing trials and to confirm that we have obtained available publications of results from completed trials.

### Inclusion and Exclusion Criteria

Table A-1 outlines inclusion criteria. We required that eligible RCTs have a total minimum sample size of 10. We required a higher minimum sample size (n=20) for other comparative studies as they typically have fewer controls for bias than RCTs. We recognize that these study design criteria excluded single-subject or single-case experimental designs that have been used to study interventions targeting sensory challenges. These studies are challenging to incorporate in a meaningful way in comparative effectiveness reviews, which attempt to evaluate the effectiveness of interventions at the population level. To mitigate the exclusion of such studies; however, we include summaries of recent reviews that have included such studies and discuss our findings in light of those in other reviews (see Findings in Relation to What is Known).

Table A-1 Inclusion criteria

Category | Criteria
Study Population | Children ages 2–12 with ASD (mean age plus standard deviation is ≤ 12 years and 11 months)
Publication Languages | English only
Admissible Evidence (study design and other criteria) | Admissible designs Randomized controlled trials, prospective and retrospective cohort studies with comparison groups, and nonrandomized controlled trials Other criteria Original research studies published from 2010—present and not addressed in prior reviews Studies must have relevant population and ≥20 participants with ASD (non-RCTs) or at least 10 total participants (RCTs) Studies must address one or more of the following for ASD:; - Outcomes of interest; - Treatment modality of interest; - Predictors or drivers of treatment outcomes (e.g., biomarkers, clinical changes); - Maintenance of outcomes across environments or contexts; - Sufficiently detailed methods and results to enable data extraction; - Reporting of outcome data by target population or intervention

ASD = Autism Spectrum Disorder; RCT = randomized controlled trial

We included studies published in English only. In the opinion of our content experts, much of the relevant literature on ASD is published in English; however, we scanned a sample of 150 non-English abstracts to gauge the number of anticipated non-English studies that would meet inclusion criteria. Two non-English studies appeared to meet our criteria. Given this small proportion of potentially eligible studies, we feel that excluding these publications is unlikely to introduce significant bias.

Eligible studies also reported one or more outcomes of interest and included children at least 2 years of age and up to and including age 12. Studies also included only children with a diagnosis of ASD (or data reported separately for children with ASD).

### Study Selection

Once we identified articles through the electronic database searches and hand-searching, we examined abstracts of articles to determine whether studies met our criteria. Two reviewers separately evaluated the abstracts of studies identified in our searches for Key Questions for inclusion or exclusion, using an Abstract Review Form (Appendix C). If one reviewer concluded that the article could be eligible for the review based on the abstract, we retained it. Following abstract review, two reviewers independently assessed the full text of each included study using a standardized form (Appendix C) that included questions stemming from our inclusion and exclusion criteria. A senior reviewer resolved disagreements between reviewers.

We conducted all abstract and full text reviews using the DistillerSR online screening application (Evidence Partners Incorporated, Ottawa, Ontario). Appendix D includes a list of excluded studies and the reasons for exclusion. Data extracted for each study are available via the Systematic Review Data Repository (http://srdr.ahrq.gov/).

### Data Extraction

The staff members and clinical experts (including two psychiatrists, two psychologists, and three epidemiologists/systematic reviewers) who conducted this review jointly developed the data extraction forms for the KQs. We designed forms to provide sufficient information to enable readers to understand the studies and to determine their quality; we gave particular emphasis to essential information related to the KQs.

The team was trained to extract data by extracting several articles into the template and then reconvening as a group to discuss the utility of the template. We repeated this process through several iterations until we decided that the templates included the appropriate categories for gathering the information contained in the articles and for potential meta-analyses. Team data extractors shared the task of initially entering information into the evidence tables. A second team member also reviewed the articles and edited all initial entries for accuracy, completeness, and consistency. A senior reviewer reconciled disagreements concerning the information reported.

The full research team met regularly during the article extraction period and discussed issues related to the data extraction process. In addition to outcomes related to the effectiveness of treatment (e.g., changes in ASD severity), we extracted all data available on harms. Harms encompass the full range of specific negative effects, including the narrower definition of adverse events.

## Data Synthesis

Studies were too heterogeneous to allow for meta-analyses. We summarized data for Key Questions qualitatively using summary tables.

## Risk of Bias Assessment of Individual Studies

We evaluated the overall methodologic risk of bias of individual studies using the ASD-specific assessment approach developed and used in our prior reviews of interventions for ASD and informed by the Methods Guide for Effectiveness and Comparative Effectiveness Reviews.^1^ This risk of bias approach considers factors related to study design, diagnostic approach, participant ascertainment, intervention characteristics, outcomes measurement, and statistical approach and includes questions such as: Did the authors report differences in or hold steady all concomitant interventions? Were outcomes coded and assessed by individuals blinded to the intervention status of the participants? For randomized controlled trials, was there an intent-to-treat analysis? Two senior investigators assessed each included study independently with disagreements resolved through discussion. Appendix C includes our risk of bias assessment form, and Appendix E includes the risk of bias ratings for each study.

## Determining Overall Risk of Bias Ratings

We used the thresholds we establish in prior reviews to assess overall high, medium or low risk of bias. We assessed the risk of bias based upon the study-defined primary outcome(s). We assessed each domain described above individually and considered the individual ratings to determine an overall quality assessment of low, moderate, or high risk of bias. We required that studies receive positive scores on questions related to randomization and diagnostic approach to be considered low risk of bias. Scores were calculated first by domain and then summed and weighted as described in Table A-2 to determine overall study risk. Studies could receive up to two points on the domains of study design, diagnostic approach, participant ascertainment, and intervention, and up to one point on the domains of outcome measurement and statistical analysis (10 total points).

Table A-2 Quality scoring algorithm

Definition and Scoring Algorithm | Rating
- ≥8/10 points, including a ++ on study design and ++ on diagnostic approach | Low risk of bias
- ≥6/10 points, including at least a + on intervention | Moderate risk of bias
- ≥5/10 points | High risk of bias

## Strength of the Body of Evidence

The assessment of the literature is done by considering both the observed effectiveness of interventions and the confidence that we have in the stability of those effects in the face of future research. The degree of confidence that the observed effect of an intervention is unlikely to change is presented as strength of evidence, and it can be regarded as insufficient, low, moderate, or high. Strength of evidence describes the adequacy of the current research, both in terms of quantity and quality, as well as the degree to which the entire body of current research provides a consistent and precise estimate of effect. Interventions that have demonstrated benefit in a small number of studies but have not yet been replicated using the most rigorous study designs will therefore have insufficient or low strength of evidence to describe the body of research. Future research may find that the intervention is either effective or ineffective. Strength of the evidence is assessed for a limited set of critical outcomes, typically those related to effectiveness of an intervention.

Methods for applying strength of evidence assessments are established in the Methods Guide for Effectiveness and Comparative Effectiveness Reviews^1^ and are based on consideration of five domains (Table A-3): study limitations, consistency in direction of the effect, directness in measuring intended outcomes, precision of effect, and reporting bias. Strength of evidence is assessed separately for major intervention-outcome pairs and incorporates data from the entire body of reviewed evidence on behavioral interventions (i.e., comparative studies—both RCTs and prospective and retrospective cohort studies—reported in the 2011 review^2^ and studies reported in the current review). We required at least one low risk of bias study for moderate strength of evidence and two low risk studies for high strength of evidence. In addition, to be considered “moderate” or higher, intervention-outcome pairs needed a positive response on two out of the three domains other than study limitations.

Table A-3 Domains used to assess strength of evidence^a^

Domain | Explanation
Study Limitations | Degree to which included studies for a given outcome have a high likelihood of adequate protection against bias (i.e., good internal validity), assessed through study design and study conduct.
Consistency | Degree to which included studies find either the same direction or similar magnitude of effect. Assessed through two main elements:; - Direction of effect: Effect sizes have the same sign (that is, are on the same side of no effect or a minimally important difference).; - Magnitude of effect: The range of effect sizes is similar.
Directness | Extent to which evidence links interventions directly to a health outcome of specific importance for the review, and for comparative studies, whether the comparisons are based on head-to-head studies. Evidence may be indirect in several situations such as:; - Outcome being graded is considered intermediate in a review that is focused on clinical health outcomes (such as morbidity, mortality).; - Data do not come from head-to-head comparisons but rather from two or more bodies of evidence to compare.; - Data are available only for proxy respondents instead of directly from patients for situations in which patients are capable of self-reporting and self-report is more reliable.
Precision | Degree of certainty surrounding an effect estimate with respect to a given outcome, based on the sufficiency of sample size and number of events. A body of evidence will generally be imprecise if the optimal information size (OIS) is not met. OIS refers to the minimum number of patients (and events when assessing dichotomous outcomes) needed for an evidence base to be considered adequately powered.
Reporting Bias | Degree of selective publishing or reporting of research findings based on the favorability of direction or magnitude of effect.

a Excerpted from Berkman et al. 2013^4^

Once we had established the maximum strength of evidence possible based upon these criteria, we assessed the number of studies and range of study designs for a given intervention-outcome pair, and downgraded the rating when the cumulative evidence was not sufficient to justify the higher rating. The possible grades were:

- High: High confidence that the evidence reflects the true effect. Further research is unlikely to change estimates
- Moderate: Moderate confidence that the evidence reflects the true effect. Further research may change our confidence in the estimate of effect and may change the estimate
- Low: Low confidence that the evidence reflects the true effect. Further research is likely to change confidence in the estimate of effect and is also likely to change the estimate
- Insufficient: Evidence is either unavailable or does not permit a conclusion.

## Applicability

We assessed the applicability of findings reported in the included literature addressing our KQs to the general population of children with ASD by determining the population, intervention, comparator, and setting in each study and developing an overview of these elements for each intervention category. We anticipated that areas in which applicability would be especially important to describe would include ASD severity, comorbidities, age at treatment, and intervention characteristics such provider, dosing/intensity, and setting. Applicability tables for each KQ are in Appendix F.

## Peer Review and Public Commentary

Researchers and clinicians with expertise in treating children with ASD and individuals representing stakeholder and user communities provided external peer review of this report. The draft report was posted on the AHRQ Web site for 4 weeks to elicit public comment. We addressed all reviewer comments, revised the text as appropriate, and documented changes and revisions to the report in a disposition of comments report that will be made available 3 months after AHRQ posts the final review on the AHRQ Web site.

## References

1 Methods Guide for Effectiveness and Comparative Effectiveness Reviews. AHRQ Publication No. 10(14)-EHC063-EF. Rockville, MD: Agency for Healthcare Research and Quality. January 2014. Chapters available at: www.effectivehealthcare.ahrq.gov
2 Warren Z, Veenstra-VanderWeele J, Stone W, Bruzek JL, Nahmias AS, Foss-Feig JH, Jerome RN, Krishnaswami S, Sathe NA, Glasser AM, Surawicz T, McPheeters ML. Therapies for Children With Autism Spectrum Disorders. Comparative Effectiveness Review No. 26. (Prepared by the Vanderbilt Evidence-based Practice Center under Contract No. 290-2007-10065-I.). AHRQ Publication No. 11-EHC029-EF. Rockville, MD: Agency for Healthcare Research and Quality. April 2011. Available at: www.effectivehealthcare.ahrq.gov/reports/final.cfm.
3 Weitlauf AS, McPheeters ML, Peters B, Sathe N, Travis R, Aiello R, Williamson E, Veenstra-VanderWeele J, Krishnaswami S, Jerome R, Warren Z. Therapies for Children With Autism Spectrum Disorder: Behavioral Interventions Update. Comparative Effectiveness Review No. 137. (Prepared by the Vanderbilt Evidence-based Practice Center under Contract No. 290-2012-00009-I.) AHRQ Publication No. 14-EHC036-EF. Rockville, MD: Agency for Healthcare Research and Quality; August 2014. www.effectivehealthcare.ahrq.gov/reports/final.cfm.
4 Berkman ND, Lohr KN, Ansari M, McDonagh M, Balk E, Whitlock E, Reston J, Bass E, Butler M, Gartlehner G, Hartling L, Kane R, McPheeters M, Morgan L, Morton SC, Viswanathan M, Sista P, Chang S. Grading the Strength of a Body of Evidence When Assessing Health Care Interventions for the Effective Health Care Program of the Agency for Healthcare Research and Quality : An Update. Methods Guide for Comparative Effectiveness Reviews (Prepared by the RTI-UNC Evidence-based Practice Center under Contract No. 290-2007-10056-I). AHRQ Publication No. 13 (4)-EHC130-EF. Rockville, MD: Agency for Healthcare Research and Quality. November 2013. Available at: www.effectivehealthcare.ahrq.gov/reports/final.cfm