# Acronyms and Abbreviations

ABC: Autism Behavior Checklist
ADOS: Autism Diagnostic Observation Schedule
AHRQ: Agency for Healthcare Research And Quality
ASD: Autism Spectrum Disorder
CARS: Childhood Autism Rating Scale
CER: Comparative Effectiveness Review
DSM: Diagnostic and Statistical Manual
G: Group
GAS: Goal Attainment Setting
IQ: Intelligence Quotient
KQ: Key Question
n: Number
NR: Not Reported
NS: Not Significant
OT/SI: Occupational Therapy with Sensory Integration
PDDBI: Pervasive Development Disorder Behavior Inventory
PDD-NOS: Pervasive Developmental Disorder – Not Otherwise Specified
PICOTS: Population, Intervention, Comparator, Outcome, Timing, Setting
PLS: Preschool Language Scale
QST: Qigong Sensory Training
RCT: Randomized Controlled Trial
SI: Sensory Integration
SOE: Strength of Evidence
SSC: Sense And Self-Regulation Checklist
TEP: Technical Expert Panel
VABS: Vineland Adaptive Behavior Scales