# Results

The literature searches yielded 13,334 citations (Figure 4). We identified 510 of these as potentially relevant full-text studies. These were retrieved for further evaluation. Overall, 339 full text articles did not meet eligibility criteria (see Appendix B for a list of rejected articles along with reasons for rejection); two additional publications were identified through a hand search of reference lists. Searching the U.S. Food and Drug Administration (FDA) database, clinicaltrials.gov, and the WHO International Clinical Trials Registry Platform did not yield any trials with results that were not already included in the report.

Figure 4 Literature flow diagram

CINAHL = Cumulative Index to Nursing and Allied Health Literature; KQ = Key Question; NRCS = nonrandomized comparative trial; RCT = randomized controlled trial; some publications reported data from the same study. The KQ3 publications included 70 cohorts, 12 NRCSs and 3 RCTs from which the cohort most closely matching usual care was extracted. Detailed reasons for exclusion of studies reviewed in full text but not considered further are presented in Appendix B.

This figure demonstrates the process by which 172 publications were eligible for this review. Of the publications eligible for Key Question 1, there were 54 publications representing 29 RCTs and 25 NRCSs. For Key Question 2, there were 8 publications, representing 7 RCTs and 1 NRCS. There are 85 citations for Key Question 3. For Key Question 4 we included 11 publications, consisting of 2 RCTs and 9 NRCSs. Key Question 5 had 14 publications reporting 10 RCTs and 1 NRCS. From electronic database searches, there were 13,334 citations. An additional 2 publications were found from hand searches of reference lists. From all of these combined, 12,825 were excluded based on abstract screening, 509 full text studies were screened and an additional 336 were excluded for the following reasons: abstract only, Case Report or Cohort with sample size less than 50, no extractable data, no outcomes of interest, no primary data, not intervention of interest, not population of interest, per ear assignment, retrospective cohort with less than 1000 subjects, retrieved in abstract only.

A total of 173 articles are included in this report. Searching the FDA database, clinicaltrials.gov, and the WHO International Clinical Trials Registry Platform did not yield any trials with results that were not already included in the report.

As shown in Figure 4, the majority of included publications (n = 85) related to KQ 3. These included prospective surgical case series that followed 50 or more children after TT placement or large (≥ 1000 subject) registry-based retrospective cohorts. There are a relative paucity of studies available for the other the main effectiveness KQs.

## Key Question 1

For children with chronic otitis media with effusion, what is the effectiveness of tympanostomy tubes (TT), compared to watchful waiting, on resolution of middle ear effusion, hearing and vestibular outcomes, quality of life, and other patient-centered outcomes?

a. What factors (such as age, age of onset, duration of effusion, comorbidities, and sociodemographic risk factors) predict which children are likely to benefit most from the intervention?
b. Does obtaining a hearing test help identify which children are more likely to benefit from the intervention?

### Eligible Studies

We identified 54 publications. Of these, there were 29 papers reporting 16 RCTs.^4, 36–63^ There were 24 publications reporting 24 NRCSs that assessed the effectiveness of TT in children with chronic middle ear effusion.^64–87^

#### Description of Randomized Trials

Among the 16 RCTs (Table 1), a majority enrolled children in the preschool and early school ages (mean age of enrolled children ranged from 1.6 to 5.4 years). Sample sizes ranged between 23 and 491. Most trials enrolled a majority of boys. The proportion of male children ranged from 48 to 82 percent. Most studies enrolled children with persistent middle ear effusion in one or both ears for periods of 2 to 6 months. Two studies included at least some patients with recurrent AOM with or without persistent middle ear effusion.^36, 49^ Most studies were conducted in the United States and Europe. The majority completed enrollment more than a decade ago. Reporting of age of onset, duration of effusion, and sociodemographic risk factors was sparse. All RCTs excluded children with major comorbidities (e.g. Down syndrome and cleft palate). For details, see Appendixes C–E.

Table 1 Summary of randomized controlled trials (RCTs)

Study Year PMID Country | Inclusion Criteria | Age (years) | Enrollment period | Comparators (N) | Hearing (measurement time in months) | MEE (followup in months)
Bernard 1991 1861917 Canada^36^ | MEE > 3 months in at least one ear | 2.5 to 7 | NR | Sulfisoxazole (65) vs. TT (60) | Mean HL (0,2,4,6,12,18) | NR
Casselbrant 2009 19819563 1997–2005 U.S.^37^ | bilateral MEE >= 3 mo, unilateral MEE >= 6 mo | 2.0 to 3.9 | 1997–2005 | TT (32) vs. TT & adenoidectomy (32) vs Myringotomy & Adenoidectomy (34) | Study entry only | Percent time with MEE (18, 36)
Chaudhuri 2006 23120310 India^38^ | Unclear | 0 to 12 | NR | Antibiotic prophylaxis (25) vs. Oral steroid (25) vs. Placebo (25) vs. TT +/− adenoidectomy (25) | | Composite cure (appearance, audiometry, tympanography)
Gates 1987 3683478 U.S.^88^ | suspected SOM with MEE persisting >= 2 months | 4 to 8 | 4/1980–6/1984 | TT (129) vs. Myringotomy (107) vs. vs. TT & Adenoidectomy (125) vs. Myringotomy & Adenoidectomy (130) | Time with abnormal hearing & time with HL >= 20 dB | Percent time with effusion & time to 1st recurrence, proportion of exams with effusion
Mandel 1989 2789777a U.S.^44^ | MEE >= 2 mo | 7 mo to 12 | 09/1979–09/1984 | TT (30) vs. Myringotomy (29) vs Control (29) | HL (0, 1,2) | Percent time with effusion (12, 24, 36)
Mandel 1989 2789777b U.S.^44^ | MEE >= 2 mo | 7 mo to 12 | 09/1979–09/1984 | TT (11) vs. Myringotomy (12)
Mandel 1992 1565550 U.S.^45^ | MEE >= 2 mo | 7 mo to 12 | 11/1981–06/1987 | TT (37) vs. Myringotomy (39) vs. Watchful waiting (4–6 months) (35) | HL (0,1,2,4) | Percent time with effusion (12, 36)
Maw 1999 10459904 UK^40, 46, 63^ | bilateral OME & HL > = 20 dB | NR | 4/1991–12/1992 | TT (92) vs. Watchful waiting (90) | HL (0, 9) | Number with at least one middle ear without fluid
MRC Multicentre Otitis Media Study Group 2012 (TARGET) 12680834 UK ^4, 47, 48^ | bilateral OME & better ear HL >= 20 dB for 3 mo | 3.25 to 6.75 | 4/1994–1/1998 | TT (126) vs. TT & adenoidectomy (128) vs. Watchful waiting (122) | HL (0,3,6,9,12,15,18,21,24)
Nguyen 2004 15126745 Canada^49^ | recurrent OM with > 3 episodes in 6 mo or 4 in 12 mo, persistent OME > 3 months, or HL > 30 dB | 1.5 to 18 | 01/1998–01/2003 | TT (16) vs. TT & adenoidectomy (18) | Included in composite outcome | Included in composite outcome
Paradise 2001 11309632 U.S.^43, 50–52, 54^ | bilateral MEE >= 3 mo, unilateral MEE >= 135 days) | < 3 | 6/1991–12/1995 | TT (216) vs. Watchful Waiting (213) | NR | Percent time with effusion (6,12,18,24)
Popova 2010 20399511 Bulgaria^55^ | bilateral MEE >= 3 mo & HL > 20 dB | 3 to 7 | 2007–2009 | TT (42) vs. Myringotomy AND Adenoidectomy (36) | HL (0,1,6,12) | Number with recurrence
Rach 1991 2070526 Netherlands^56^ | bilateral OME >= 6 mo | > 2 | NR | TT (22) vs. Watchful waiting (for 9 months then tubes if needed) (21) | NR | NR
Rovers 2000 10969126 Netherlands^41, 42, 57–60^ | bilateral persistent OME 4–6 months | > 9 mo | 1/1996–4/1997 | TT (93) vs. Watchful waiting (94) | HL (0,6,12) | Percent with bilateral OME (3,6,9,12)
Velopic 2001 21397957 Croatia^61^ | unilateral or bilateral OME >= 3 mo | 2 to 12 | 2004–2009 | TT (56) vs. TT & adenoidectomy | Average and frequency specific air bone gap (0, 6+) | Resolution of effusion at 6+ months postoperative.
Vlastos 2011 21205368 Greece^62^ | sleep-disordered breathing & bilateral OME | 3 to 7 | 5/2007–5/2008 | TT & Adenoidectomy (25) vs. Myringotomy & Adenoidectomy (27) | HL (0,6,12)

TT: Tympanostomy tubes, HL: Hearing thresholds (time in months), OME: Otitis Media with effusion, MEE: Middle ear effusion, NR: not reported, mo: months

As illustrated in Figure 5, and detailed in Table 1, the RCTs compare multiple interventions: TT, TT with adenoidectomy, myringotomy with adenoidectomy, myringtomy alone, adenoidectomy alone, oral corticosteroid treatment, antibiotic prophylaxis, and watchful waiting.

Figure 5 Evidence graph for the 16 RCTs

Evidence graph for the 16 RCTs (10 comparing pairs, 4 comparing triplets, and 2 comparing quadruplets of treatments) identified in the systematic review. Of the 28 possible comparisons that are possible, 16 were examined in the RCTs. The network plot consists of nodes representing the interventions being compared and edges representing the available direct comparisons. The number of studies that include each comparison is indicated next to each edge (connecting lines with thickness proportional to this number).

TT= tympanostomy tubes; RCTs= Randomized Control Trials

Evidence graph for the 16 RCTs (10 comparing pairs and 4 comparing triplets and 2 comparing quadruplets of treatments) identified in the systematic review. Of the 28 possible comparisons that are possible, 16 were examined in the RCTs. The interventions in the network include; Tympanostomy tubes, Tympanostomy tubes and Adenoidectomy, Tympanostomy with variable use of Adenoidectomy, Watchful waiting, Myringtomy, Myringotomy and Adenoidectomy, antibiotic prophylaxis and oral glucocorticoids. The thickness of the edges corresponds to the number of studies which provide direct comparisons. The most common direct comparison is Tympanostomy tubes with watchful waiting, with somewhat fewer direct comparisons between Tympanostomy tubes and Myringotomy alone, Tympanostomy tubes vs. Tympanostomy tubes with Adenoidectomy, and Tympanostomy tubes and Adenoidectomy with Myringotomy and Adenoidectomy.

#### Risk of Bias: RCTs

Overall, RCTs that compared TT and nonsurgical arms had high risk of bias, due to lack of blinding of participants and care providers (blinding is not feasible given the intervention). With the exception of Maw 1999^46^ and Gates 1987,^88^ trials had unclear (did not report) or had high risk of bias for lack of blinding of outcome assessors. The details of random sequence generation were unclear in the majority of studies (unclear risk of bias). Randomization sequence generation was adequately described in four RCTs.^4, 52, 62, 88^ The Rach 1991 RCT reported that randomized allocation was performed only for the first 5 of 43 children entering the trial; each subsequent child was allocated to the treatment group that would lead to the smallest imbalance. While this allocation scheme is reminiscent of “minimization”-based randomized allocation schemes, the RCT was judged to have a high risk of confounding bias.^56^ All studies had at least some incomplete outcome data for some subjects. The proportion of subjects with missing data increased in studies with longer term followup. The TARGET study employed missing data imputation to limit attrition bias.^4^ Most studies reported an intention to treat analysis. However, in many studies, there was a high rate of crossover to surgical interventions (TT, adenoidectomy, or both).

#### Description of Nonrandomized Comparative Studies

Of the 25 NRCSs,^64–87^ 9 compared TT with watchful waiting or medical treatment and 2 compared TT with myringotomy. Outcomes evaluated included hearing levels, persistence of middle ear effusion and composite outcomes (cure, recurrence). These studies are summarized in Table 2. For futher details, see Appendices C–E.

Table 2 Summary of nonrandomized comparative studies (NRCSs)

Study, Year, PMID, Country | Enrollment period | Comparators (N) | Special populations | Covariate adjusted | Outcome(s)
Coyte 2001 11309633 Canada^72^ | 1992–1997 | TT (10602) & adenoidectomy vs. TT (26714) | | Yes | Rate of rehospitalization; reinsertion of TT
De Beer 2004 15224825 Netherlands^74^ | 2001 | TT (51) vs. OME without TT (132) vs. control (174) | | Yes | Hearing levels at 18 years
Forquer 1982 6184891 U.S.^67^ | NR | TT (177) vs. medical treatment & delayed TT (170) vs. medical treatment (153) | | No | Hearing level; Middle ear effusion
Grievink 1993 8246466 Netherlands^70^ | 9/1990–2/1991 | TT (37) vs. OME (151) vs. control (82) | | Yes | Language ability
Hu 2015 26429601 U.S.^85^ | 2014 | TT (12) vs. TT & adenoidectomy or adenotonsillectomy (8) | | No | Hearing level
Hubbard 1985 4039792 U.S.^66^ | 1/1979 | Early TT (24) vs. late TT (24) | Cleft palate | No | Hearing level
Kadhim 2007 17279052 Australia^76^ | 1981–2004 | TT (36532) vs. TT & adenoidectomy (7534) | | Yes | Need for further surgery
Kobayashi 2012 22386274 Japan^79^ | 1996–1999 | Early TT (82) vs. late TT (bilateral: 6 mo, unilateral: 3 mo) (100) | Cleft palate | No | Language development
Kuşcu 2015 26545930 Turkey^86^ | 2008–2013 | early TT (67) vs. late TT (22) vs. no TT (65) | Cleft palate | No | Hearing level, otoscopic findings
Li 2015 26281253 China^84^ | 2002 – 2012 | TT (248) vs. Myringotomy (276) | Cleft palate | No | Cure, Recurrence
Li 2015 26281253 China^84^ | 2003 – 2012 | TT (78) vs. Myringotomy (168) | Adenoidal hypertrophy | No | Cure, Recurrence
Marshak 1980 6778336 Israel^68^ | NR | TT (29) vs. myringotomy & adenoidectomy (29) | | No | Middle ear effusion
Motta 2006 17465378 Italy^77^ | 1/1/2001–12/31/2001 | TT & adenoidectomy (34) vs. adenoidectomy (40) | | No | Middle ear effusion
Niclasen 2016 27063746 Denmark^87^ | 2001–2002 | 4+ episodes of OM (569) vs. 4+ episodes of OM& TT (999) | | Yes | Behavioral and Learning Difficulties
Peters 1994 8195687 Netherlands^69^ | 9/1990–2/1991 | . | | Yes | Educational attainment, Reading & Spelling
Reiter 2009 19929085 Germany^78^ | NR | TT & palate cleft repair (50) vs. palate cleft repair (66) | Cleft palate | No | Hearing level
Robson 1992 1431515 UK^65^ | 1976–1988 | TT (38) vs. control (32) | Cleft palate | No | Hearing level; Middle ear effusion
Schilder 1997 9372253 UK^71^ | 1990 | TT (56) vs. control (102) | | Yes | Hearing levels; Language & Educational achievement
Stenstrom 2005 16330739 Canada^75^ | 1985–1989 | TT (38) vs. sulfisoxazole (27) | | No | Long term hearing thresholds
Tian 2015 26103659 China^83^ | 1/2001–6/2013 | TT & Adenoidectomy (40 ears) vs. Myringotomy & Adenoidectomy (58 ears) | | No | Composite Outcome (symptoms, otoscopy, hearing level, tympanography)
Wolter 2012 22883987 Canada^80^ | 1991–2009 | TT (26) vs. medical treatment (18) | Primary ciliary dyskinesia | No | Hearing level; Middle ear effusion; Need for further surgery
Xu 2003 12930655 China^73^ | 9/1997–5/2000 | TT & palate cleft repair (31) vs. palate cleft repair (31) | Cleft palate | No | Hearing level
Yagi 1977 321716 Sudan^64^ | NR | TT & myringotomy & adenoidectomy (100) vs. adenoidectomy (100) | | No | Middle ear effusion
Yousaf 2012 23855103 Pakistan^81^ | 6/2008–12/2011 | TT (44) vs. myringotomy (26) | | No | Middle ear effusion
Youssef 2013 24265883 Egypt^82^ | 3/2007–1/2009 | TT & myringotomy +/− adenoidectomy (86) vs. laser myringotomy +/− adenoidectomy (86) | | No | Middle ear effusion

TT: Tympanostomy tubes, NR: not reported, mo: months

Six studies evaluated comparisons of children with cleft palate who had early vs. delayed vs. medical treatment of chronic OME and reported outcomes related to language development, hearing levels, persistence of middle ear effusion. One study compared TT with medical treatment in children with primary ciliary dyskinesia and evaluated hearing levels, persistence of middle ear effusion and need for further surgery.

Eight studies compared TT with TT & adenoidectomy, adenoidectomy alone or adenoidectomy & myringotomy.

#### Risk of Bias: Nonrandomized Comparative Studies

Only five studies used matching or multivariable regression methods to adjust for potential confounders (e.g. baseline severity of middle ear disease). See Appendix F for detailed risk of bias assessments. Generally, the studies that did not adjust for confounding are at high risk of bias.

### Outcomes: Nonrandomized Comparative Studies

The outcomes of NRCSs that evaluated behavioral, language and educational outcomes are summarized in Table 10.

Table 10 Cognitive, verbal, behavioral, and quality of life outcomes

Study, year Design (N) | Outcomes: number reported (number statistically significant^*^)
Study, year Design (N) | Cognitive | Verbal | Behavioral | Quality of Life
Rach 1991 RCT (43)^56^ | | 2 (0)
Niclasen 2016 NRCS (1568)^87^ | 3(nr) | | 12 (nr)
Rovers 2000 RCT (187)^58^ | | 2 (0)
Hall 2009 RCT (136)^40^ | 10 (2) | 6 (0) | 6 (1)
Maw 1999 RCT (127)^46^ | | 4 (0) | 2 (0)
Vlastos 2011 RCT (45)^62^ | | | | 1 (0)
Paradise, 2001, 2003, 2004, 2005, 2007 RCT/NRCS (402/729)^50–54^ | 15 (2) | 18 (4) | 14 (2) | 4 (0)
Peters 1994 NRCS (188)^69^ | 15 (1) | 5 (0)
Grievink 1993 NRCS (183)^70^ | 1 (0) | 9 (0)
Schidler 1997 NRCS (27)^71^ | | 5 (2)

* No statistically significant effect of intervention on outcome (in either direction) reported

† No statistical comparison reported.

RCT= Randomized Control Trial; NRCS= Nonrandomized Comparative Study, NR= Not Reported

The Coyte 2001 report analyzed hospital discharge records and found that treatment with TT and adenoidectomy compared with TT alone was associated with a reduction in the likelihood of reinsertion of TT (RR 0.5 [95% CI: 0.5–0.6]) and the likelihood of readmission for conditions related otitis media (RR 0.5 [95% CI: 0.5–0.6]), with greatest benefit in children three years of age or older.^72^

Schilder 1997 compared hearing levels and mean duration of otitis media with effusion (OME) at seven to eight years between children treated with TT at two to four years of age, with a (retrospectively) matched group of children who were not treated surgically. Pure tone average hearing levels measured at 0.5 to 4kHz were 11.4 and 8.1 dB (P=0.19) for treated and control ears, respectively. Similarly, mean OME percentages were not significantly different between groups (P ≤ 0.08).^71^

### Hearing Outcomes: RCTs

Hearing thresholds (in dB) were reported by arm in 10 RCTs at various time points, allowing estimation of comparative effects between interventions. Pure tone average (typically averaged over 500, 100, 2000, and 4000 Hz) hearing thresholds were extracted. Hearing thresholds were variably reported as: averaged over both ears, best and worst ear, and right and left ear. When multiple averages were reported, we extracted for analysis the worst ear and the right ear. Six RCTs reported hearing thresholds at 1 to 3 months (classified as “early”).^4, 36, 44, 45, 55^ Five RCTs reported hearing thresholds at 12 to 24 months (classified as “late”).^4, 36, 55, 58, 62^ The remaining 6 RCTs did not report information in enough detail to include in quantitative analyses and are described separately. The Mandel 1989 RCT stratified children by preintervention hearing thresholds.^44^ Patients with no significant hearing loss (≤ 20 dB bilaterally or ≤ 40 dB unilaterally) were randomized to watchful waiting, myringtomy, or TT. The 23 patients with significant hearing loss were randomized to myringotomy or TT only. We have included these two groups as separate RCTs in the meta-analysis.

Figure 6 shows the topology of the network for early hearing thresholds at 1 to 3 months. TT were the most common comparator, being compared in head-to-head trials with four interventions (all except for myringotomy with adenoidectomy). TT, TT with adenoidectomy, myringotomy, and watchful waiting have each been compared with at least two other interventions. By contrast antibiotic prophylaxis is compared only with TT and in only one trial, and myringotomy with adenoidectomy is compared only with TT with adenoidectomy, again only in one trial.

Figure 6 Network graph for early (1–3 months) comparisons for hearing thresholds

The network plot consists of nodes representing the interventions being compared and edges representing the available direct comparisons. The number of studies that include each comparison is indicated next to each edge (connecting lines with thickness proportional to this number).

A topology map of the network used for meta-analysis of different interventions in children with chronic middle ear effusion. Six classes of intervention are displayed; including Tympanostomy tubes, Tympanostomy tubes and Adenoidectomy, Watchful waiting, Myringotomy, Myringotomy and Adenoidectomy and antibiotic prophylaxis. Of the 15 possible pairwise contrasts, 7 are covered by direct comparisons. Three studies provided direct comparisons between Tympanostomy tubes and watchful waiting. Three studies also allow direct comparisons of Tympanostomy with myringotomy. Several comparisons were directly compared in only a single study: Antibiotic prophylaxis with Tympanostomy, Tympanostomy and Adenoidectomy with Tympanostomy, or Watchful waiting, or Myringtomy and Adenoidectomy.

Table 3 shows the combined direct and indirect data from the network meta-analysis for early hearing thresholds for all possible comparisons between the treatments. Bearing in mind that a difference in hearing thresholds of 10 dB is likely clinically important, it appears that interventions that ventilate the middle ear (TT and TT and adenoidectomy) improved hearing thresholds by −9.1 dB and −10.3 dB respectively, compared to watchful waiting, with 95% credible intervals that exclude a null effect in the 1- to 3-month time frame.

Table 3 Differences in early hearing thresholds (in dB, 1–3 months)

TT | −1.2 (−9.8, 7.2) | 6.8 (0.3, 12.2) | −1.4 (−14.0, 11.1) | 9.1 (−0.4, 18.5) | 9.1 (3.2, 14.5)
1.2 (−7.2, 9.8) | TT + Adenoidectomy | 8.0 (−2.1, 17.2) | −0.2 (−9.4, 9.0) | 10.3 (−2.4, 23.1) | 10.3 (1.6, 18.6)
−6.8 (−12.2, −0.3) | −8.0 (−17.2, 2.1) | Myringotomy | −8.2 (−21.2, 5.9) | 2.3 (−8.3, 14.0) | 2.3 (−4.0, 9.2)
1.4 (−11.1, 14.0) | 0.2 (−9.0, 9.4) | 8.2 (−5.9, 21.2) | Myringotomy + Adenoidectomy | 10.5 (−5.1, 26.3) | 10.5 (−2.4, 22.9)
−9.1 (−18.5, 0.4) | −10.3 (−23.1, 2.4) | −2.3 (−14.0, 8.3) | −10.5 (−26.3, 5.1) | Antibiotic prophylaxis | 0.0 (−11.3, 10.7)
−9.1 (−14.5, −3.2) | −10.3 (−18.6, −1.6) | −2.3 (−9.2, 4.0) | −10.5 (−22.9, 2.4) | −0.0 (−10.7, 11.3) | Watchful waiting

Differences in hearing thresholds (dB) and 95% Credible Intervals in early (at 1–3 months) hearing thresholds among the 6 treatments in Figure 6. Each cell contains the difference of the comparison of the intervention in the corresponding row versus the intervention in the corresponding column. Negative numbers imply better outcomes for the first.

Table 4 lists the probabilities derived from the network meta-analysis that an intervention is the first, second, etc., most effective with respect to early hearing thresholds. Table 5 aggregates these probabilities and lists the probability that an intervention is among either among the three most effect or the three least effective. TT placement has a 97 percent probability of being the most effective intervention, followed by TT and adenoidectomy (96%) and myringotomy and adenoidectomy (91%). Watchful waiting has high probability (99%) of being one of three least effective interventions, together with antibiotic prophylaxis and myringotomy alone.

Table 4 Probabilities (percent) that an intervention ranks as the i-th most effective with respect to early hearing thresholds

Intervention | 1st | 2nd | 3rd | 4th | 5th | 6th
TT | 19 | 22 | 56 | 2 | 0 | 0
TT + Adenoidectomy | 32 | 49 | 15 | 3 | 1 | 0
Myringotomy | 1 | 2 | 5 | 59 | 24 | 9
Myringotomy + Adenoidectomy | 47 | 24 | 20 | 4 | 2 | 2
Antibiotic prophylaxis | 1 | 2 | 3 | 19 | 28 | 46
Watchful waiting | 0 | 0 | 1 | 12 | 44 | 42

Table 5 Probabilities (percent) that an intervention is among the three most effective with respect to early hearing thresholds

Intervention | Probability (%) of being among the 3 most effective interventions | Probability (%) of being among the 3 least effective interventions
TT | 97 | 3
TT + Adenoidectomy | 96 | 4
Myringotomy | 8 | 92
Myringotomy + Adenoidectomy | 91 | 9
Antibiotic prophylaxis | 6 | 94
Watchful waiting | 1 | 99

As illustrated in Figure 7, when compared with watchful waiting at 1 to 3 months followup, mean hearing thresholds improved (decreased) by average of 9.1 dB following TT and by 10 dB following TT with adenoidectomy. Credible intervals for these effects exclude zero. The credible intervals for comparisons between watchful waiting and myringotomy alone, myringotomy with adenoidectomy, and oral antibiotic prophylaxis were wide, but did not exclude a null effect.

Figure 7 Early (1 to 3 months) decrease (improvement) in mean hearing thresholds compared with watchful waiting

CrI= Credibility Interval; TT=Tympanostomy Tubes

Illustrates the network meta-analysis combining direct and indirect evidence for the effectiveness of various interventions at 1 to 3 months, compared with watchful waiting. Mean hearing levels improved (decreased) by average of 9.1 dB (95% credible interval: −14 to −3.4) following Tympanostomy tubes, and by 10 dB (95% credible interval: −19.0 to −1.9) following Tympanostomy tubes with adenoidectomy. Credible intervals for these effects exclude zero. The decrease in mean hearing levels for Myringotomy compared to watchful waiting was 2.3 dB (95% credible interval: −9.2 to 3.9). The credible intervals for comparisons between watchful waiting and myringotomy alone, myringotomy with adenoidectomy, and oral antibiotic prophylaxis were wide and include zero.

Figure 8 shows the topology of the network for late (12 to 24 month) hearing thresholds.

Figure 8 Network diagram of late (12–24 months) comparisons for hearing thresholds

The network plot consists of nodes representing the interventions being compared and edges representing the available direct comparisons. The number of studies that include each comparison is indicated next to each edge (connecting lines with thickness proportional to this number).

A topology map of the network of available comparisons used for meta-analysis of different interventions in children with chronic middle ear effusion. Five classes of intervention are displayed; including Tympanostomy tubes, Tympanostomy tubes and Adenoidectomy, Watchful waiting, Myringotomy and Adenoidectomy and antibiotic prophylaxis. Of the 10 possible pairwise contrasts, 5 are covered by direct comparisons. Two studies provided direct comparisons between Tympanostomy tubes and watchful waiting, and two provide the comparison between Adenoidectomy with Tympanostomy vs. Adenoidectomy vs Myringotomy and Adenoidectomy. All of the other direct comparisons (Tympanostomy tubes vs. Antibiotic prophylaxis, Tympanostomy and Adenoidectomy vs. Tympanostomy or Watchful waiting.

Table 6 shows combined direct and indirect data from the network meta-analysis for late hearing thresholds for all possible comparisons between the treatments. Bearing in mind that a difference in hearing thresholds of 10 dB is likely clinically important, none of the point estimates for improvement in hearing loss are of this magnitude, and credible intervals are wide and include the null effect. However, there is a trend suggesting that interventions including adenoidectomy (TT with adenoidectomy) may be more effective than watchful waiting.

Table 6 Differences in late hearing thresholds (in dB, 1–3 months)

Myringtomy & Adenoidectomy | 4.6 (−3.9, 12.0) | 4.3 (−2.4, 9.9) | 0.5 (−4.1, 4.3) | 4.3(−2.1, 10.2)
−4.6 (−12.0, 3.9) | Prophylaxis | −0.3 (−5.4, 4.7) | −4.2 (−10.7, 2.8) | −0.32 (−6.2, 6.2)
−4.3 (−9.9, 2.4) | 0.3 (−4.7, 5.4) | TT | −3.8 (−8.2, 0.8) | 0.01 (−3.3, 3.9)
−0.5 (−4.3, 4.1) | 4.1 (−2.8, 10.7) | 3.8 (−0.8, 8.2) | TT & Adenoidectomy | 3.8 (−0.6, 8.5)
−4.3 (−10.2, 2.1) | 0.32 (−6.2, 6.2) | 0.0 (−3.9, 3.3) | −3.8 (−8.5 0.6) | Watchful waiting

Differences in hearing thresholds (dB) and 95% Credible Intervals in early (at 1–3 months) hearing thresholds among the 5 treatments in Figure 8. Each cell contains the difference of the comparison of the intervention in the corresponding row versus the intervention in the corresponding column. Negative numbers imply better outcomes for the first.

Table 7 lists the probabilities derived from the network meta-analysis that an intervention is the first and second most effective with respect to early hearing thresholds. Table 8 aggregates these probabilities and lists the probability that an intervention is among either the three most effect or the three least effective. At 12 to 24 months, interventions that include adenoidectomy (TT & Adenoidectomy and Myringotomy & Adenoidectomy) have the highest probability of being most effective, whereas watchful waiting, TT alone, and antibiotic prophylaxis all have probability of 90 percent or greater of being least effective.

Table 7 Probabilities percent) that an intervention ranks as the i-th most effective with respect to late hearing thresholds

Intervention | 1st | 2nd | 3rd | 4th | 5th
TT | 1 | 4 | 27 | 48 | 21
TT + Adenoidectomy | 33 | 59 | 5 | 2 | 1
Myringotomy + Adenoidectomy | 59 | 29 | 6 | 3 | 3
Antibiotic prophylaxis | 6 | 5 | 26 | 18 | 46
Watchful waiting | 1 | 3 | 37 | 29 | 30

TT= Tympanostomy tube

Table 8 Probabilities (percent) that an intervention is among the two most effective with respect to late hearing thresholds

Intervention | Probability (%) of being among the 3 most effective interventions | Probability (%) of being among the 3 least effective interventions
TT | 5 | 95
TT & Adenoidectomy | 92 | 8
Myringotomy & Adenoidectomy | 88 | 12
Antibiotic prophylaxis | 10 | 90
Watchful waiting | 4 | 96

TT= Tympanostomy tube

As shown in Figure 9, by 12 to 24 months, the mean difference in hearing thresholds for TT alone, compared to watchful waiting is now centered on zero. The point estimates suggest that interventions that include adenoidectomy (TT with adenoidectomy and myringotomy with adenoidectomy) are more likely to be effective at 12 to 24 months, although 95% credible intervals do not exclude a zero mean difference.

Figure 9 Late (12–24 months) decrease (improvement) in mean hearing thresholds compared with watchful waiting

TT= Tympanostomy tube; CrI= Credibility Interval

Illustrates the results of the network meta-analysis combining direct and indirect evidence for the effectiveness of various interventions at 12 to 24 months, compared with watchful waiting. The mean improvement in hearing levels for Tympanostomy tubes is −0.35 dB (95% Credible interval: −4.0 to 3.4). The point estimate for Myringotomy and Adenoidectomy is −4.3 dB (95% Credible interval: −10, 2.3) and the estimated decrease for Tympanostomy and Adenoidectomy is −3.8 dB (95% credible interval: −8.6 to 0.6).

The results for the studies that reported measuring hearing thresholds, but did not report mean hearing thresholds needed for inclusion in the network meta-analysis are summarized below. In the MRC Multicentre Otitis Media Study Group 2004 report outcomes of a speech-in-noise automated toy test (SiN ATT), the authors hypothesized that a measure of understanding of speech in noisy situations may tap the disability experienced by children with OME. This study allocated children to receive TT, with or without adenoidectomy, or to medical management only and included 47 of 68 children also enrolled in the TARGET trial. They reported a significant treatment by baseline SiN ATT interaction (P=0.17), and concluded that children with poor baseline SiN ATT are those most likely to benefit from surgery.^48^ Chaudhuri 2006 reported a comparison of hearing thresholds between groups of children randomized to various medical treatments, placebo, or TT with or without adenoidectomy.^38^ D’Eredità 2006 reported that hearing thresholds were normal at one year in both arms of a study comparing laser myringotomy to myringtomy with TT tubes in children, aged 2 to 6 years.^39^ Gates 1985 reported in a trial of children 4 to 8 years of age (54 week followup) that those randomized to myringotomy alone experienced 16 weeks of abnormal hearing (pure-tone average of 20 dB or greater) compared to 11 weeks in those who received TT (P = 0.001). Gates 1987 reported that children treated with adenoidectomy, TT, and adenoidectomy had normal hearing (< 20 dB) in the better ear 90 to 93 percent of the time, as compared with 81 percent of the time (P < 0.001) in group treated with myringotomy alone.^89^ Paradise 2001 reported measuring hearing thresholds, but did not report the results for the comparison of hearing thresholds.^52^ Velopic 2011 found no postoperative (after more than six months) differences in average pure tone audiometry or resolution of middle ear effusion between children treated with TT & adenoidectomy and those treated with adenoidectomy alone. Average air bone gap at 2000 Hz was lower in the TT & adenoidectomy group (P=0.03).^61^

### Duration of Effusion

Six RCTs ^37, 44, 45, 52, 88^ reported the mean proportion of time with middle ear effusion. By multiplying this proportion by followup time in weeks, we estimate comparative effectiveness of interventions expressed as a mean difference in duration of effusion. Figure 10 shows the topology of the network for comparisons of the duration of middle ear effusion. Three trials directly compare TT and watchful waiting. The other comparators, which contribute indirect evidence, are myringotomy, myringtomy with adenoidectomy, TT and adenoidectomy.

Figure 10 Network graph for duration of middle ear effusion

The network plot consists of nodes representing the interventions being compared and edges representing the available direct comparisons. The number of studies that include each comparison is indicated next to each edge (connecting lines with thickness proportional to this number).

A topology map of the network of available comparisons used for meta-analysis of different interventions in children with chronic middle ear effusion. Five classes of intervention are displayed; including Tympanostomy tubes, Tympanostomy tubes and Adenoidectomy, Watchful waiting, Myringotomy and Myringotomy with Adenoidectomy. Of the 10 possible pairwise contrasts, 7 are covered by direct comparisons. Four studies provided direct comparisons between Tympanostomy tubes and Myringotomy. Three studies provide the comparison between Tympanostomy tubes and Watchful waiting.

Figure 11 shows a trend toward greater effectiveness for TT with adenoidectomy than TT alone. However, credible intervals are wide and cannot exclude a null effect for all interventions.

Figure 11 Decrease (improvement) in mean duration of middle ear effusion compared with watchful waiting

TT= Tympanostomy tube, CrI= Credibility Interval

Illustrates the results of the network meta-analysis combining direct and indirect evidence for the effectiveness of various interventions in decreasing mean duration of middle ear effusion (in months), compared with watchful waiting. The estimated relative decrease for Tympanostomy tubes and Adenoidectomy is −23 months (95% credible interval −56 to 9.9). For Tympanostomy tubes the decrease is −17 months (95% credible interval −40.0 to 4.9). The mean decrease for Myringotomy and Adenoidectomy is −14.0 months (95% credible interval −47 to 19.0) and the decrease for Myringotomy alone is −6.9 months (95% credible interval −32.0 to 17). All of the 95 percent credible intervals overlap the null effect.

As summarized in Table 9, TT and adenoidectomy and TT alone have moderately high probability (79% and 62%, respectively) of being the most effective interventions to decrease mean duration of middle ear effusion. Conversely, watchful waiting has a 94 percent probability of being among the three least effective interventions.

Table 9 Probabilities (percent) that an intervention is among the two most effective with respect to duration of MEE

Intervention | Probability (%) of being among the 2 most effective interventions | Probability (%) of being among the 3 least effective interventions
TT | 62 | 38
TT + Adenoidectomy | 79 | 21
Myringotomy + Adenoidectomy | 12 | 88
Antibiotic prophylaxis | 41 | 59
Watchful waiting | 6 | 94

TT= Tympanostomy tube; MEE= Middle Ear Effusion

### Quality of Life and Patient-Centered Outcomes

Nine studies (5 RCTs, 4 NRCSs, and one that combined both designs) in 13 papers reported on 134 quality of life and patient-centered outcomes in 1665 children over multiple time points and arms. These studies reported only 14 outcomes with significant results (see Table 10).^40, 46, 50–54, 56, 58, 62, 69–71, 87^ The results varied in magnitude and direction, even across subscales of the same test.

Five studies reported on 43 different IQ and other cognitive outcomes. Of these, five had significant results. Paradise found that children who were not eligible for randomization into a RCT for tubes because their otitis media was below the threshold had a significantly better result in the spelling subtest of the of the Woodcock-Johnson III Tests of Achievement, but not on any other subtest at ages 9 to 11. However, they found that the group included in the trial and randomized to early intervention with tubes had a better outcome on overall functioning in the Impairment Rating Scales, also at 9 to 11 years of age.^54^ Peters 1994 found that after almost eight years, kids who had received TT in a nonrandomized study did significantly better on teacher’s evaluation of their narrative writing skills, though not their reading or math scores.^69^ Similarly, Hall 2009 found that at age 4.5 children who had been randomized to early surgery had better writing (adjusted OR 3.74, 95%CI 1.51 to 9.27) and language (adjusted OR 3.45, 95% CI 1.42 to 8.39) scores at school entry, though not better math or reading scores.^40^

Seven of the eight studies reported on 51 verbal outcomes, of which six were found to have significant differences. Paradise found a significant difference in nonword repetition at 4 years of age between children randomized to early versus delayed tympanostomy, and at 6 years of age among children randomized to early versus delayed tympanostomy, those who refused randomization, and those who were not deemed eligible due to lack of severity of OME. At both time points, the delayed treatment group performed slightly better (mean difference at 3 years −3.4, 95% CI −6.2 to −0.7; mean difference at 4 years −2, 95% CI −4.1 to −0.1). In grade 4, they found that those not eligible performed significantly better than both study arms on an oral reading fluency test, though those results were not replicated at any other time point. The not eligible group had significantly worse outcomes compared to the early treatment and randomization consult withheld groups on the Children’s Version of the Hearing in Noise Test at 9 to 11 years old.^50–54^ In a small study of 27 children, Schilder 1997 found a significant difference in two language measure outcomes, but not on the three others. In word forms production, the tubes group performed significantly better (mean difference 26.4, SD 0.92), as well as in the auditory discrimination measure (mean difference 0.08, SD 0.03).^71^

Four of the nine studies reported on 35 behavioral outcomes, of which three had significant findings. Paradise found that the early surgery group performed better on the Child Behavior Checklist total problems subscale (largest mean difference 2; 95% CI 0.1 to 4.8) than the other groups at ages 9 to 11. At the same age, the early intervention group performed better on the Disruptive Behavior Disorders Rating Scale, impulsivity and overactivity factor subscale (largest mean difference 2; 95% CI 0.1 to 4.8)^54^ Niclasen reported a NRCS of performance on the Strengths and Difficulties Questionnaire (multiple subscales), parent and teacher version. They concluded that their findings suggest and association between 4 or more episodes of early otitis media treated with TT and behavioral and learning difficulties later in childhood.^87^ However, they do not report statistical tests of the contrasts between treated and untreated children.

Only two studies reported on quality of life outcomes: Paradise reported on measures of parental stress at various ages,^50–54^ and Vlastos 2011 reported on pediatric health related quality of life.^62^ Neither found any significant differences. Full details for all outcomes are in Appendix G.

## Key Question 2

For children with recurrent acute otitis media, what is the effectiveness of tympanostomy tubes (TT), compared to watchful waiting with episodic or prophylactic antibiotic therapy, on the frequency and severity of otitis media, quality of life, and other patient-centered outcomes?

### Description of Comparative Studies

We identified 8 publications, reporting on 7 RCTs^90–96^ and 2 NRCSs.^8, 93^ A total 1049 patients were randomized. The Mattila 2003 paper described two groups, an RCT which randomly allocated treatment in 137 patients, and a NRCS in which parental choice determined treatment in169 patients.^93^ Grindler 2014, reported a cross-sectional comparison of quality of life outcomes in 1208 patients.^8^

#### Comparators

Three RCTs^90–92^ compared TT placement with daily oral antibiotic prophylaxis. Two of these studies included a comparison with placebo,^90, 91^ and Kujala 2012 compared TT placement with no treatment.^95^ The effectiveness of TT alone vs TT with adenoidectomy was evaluable in three studies.^93–95^

#### Population Characteristics

Inclusion criteria were similar across studies, all required patients to have had three or more episodes of AOM in the preceding 6 months, or (in three studies) 4 or more episodes in past 12 to 18 months.

Studies varied on whether they required the presence or absence of middle ear effusion. Gonzalez 1986, El Sayed 1996, Mattila 2003 and Hammaren-Malmi 2005 did not exclude patients with otitis media with effusion.^90, 92–94^ Conversely, Kujala 2012 and Casselbrant 1992 required patients to be free of middle ear effusion at time of assessment for surgery. ^91, 95^ For study details, see Appendixes C–E.

#### Risk of Bias

The methodological and reporting quality of the included studies are generally of concern. In the RCTs of patients with recurrent AOM, randomization and allocation concealment were appropriately implemented in only one study.^95^ Comparison groups were dissimilar or the comparability was unclear in most studies.^90, 92, 93^ Blinding was partially implemented in only one study.^91^ Randomization, group similarity and blinding could not be assessed in Hammarén-Malmi 2005.^94^

The cross-sectional NRCS was rated as high for risk of confounding bias (lack of adjustment for potential confounders and potential for selection bias).^8^

### Outcomes

#### Randomized Comparative Studies

##### Frequency and Severity of Recurrent Acute Otitis Media

We did not quantitatively pool the results, primarily because of the small number of studies and substantial heterogeneity in reported outcomes. The majority of studies were done prior to widespread use of the conjugate pneumococcal vaccine, in an era where antibiotic resistance was less common and prophylactic oral antibiotic therapy was more commonly used in clinical practice. Results are summarized by comparator below.

##### TT Versus Placebo or No Treatment

Gonzalez 1986 reported on two related outcomes: the number of children with no further episodes of acute otitis media and the number of ear infections per child during the 6 month followup period (attack rate). In the placebo group, three of 20 children had no further episodes of AOM, compared to 12 of 22 in the TT group (p=0.01). The placebo group had an attack rate of 2.0 compared to the TT group, which had an attack rate of 0.86 (p=0.006).

Casselbrant 1992 also reported the number of new episodes per group divided by the total number of child years of followup. In the placebo group, this rate was 1.08 versus 1.02 in the TT group (p=0.25). In the placebo group, 40 percent had no further episodes of AOM, compared to 35 percent in the TT group. However, TT placement significantly decreased the percentage of time with AOM compared to placebo (P<0.001).

Kujala 2012 reported failure rate (defined as at least two episodes of AOM in 2 months, three in 6 months or persistent effusion lasting at least 2 months), percent of children with no recurrent AOM, cumulative number of AOM episodes, and one year incidence rates. There was an absolute difference in the proportion of failures of −13 percent (95% CI −25 to – 01, P = 0.04), between the TT and control groups. Thus 7.7 children would need to be treated with TT to prevent one additional failure. The one-year incidence rate (infections per child per year) was 0.55 (95% CI −0.93 to −0.17) lower in the TT group compared to the control group.^95^

##### TT Versus Antibiotic Prophylaxis

In the Gonzalez 1986 RCT, 54.5 percent of children in the TT group and 24 percent in the sulfisoxazole prophylaxis group had no recurrent AOM (P = 0.02). The attack rate was 0.86 infections per child in the TT group and 1.4 in prophylaxis group (P = 0.08).^90^

Casselbrant 1992 reported a rate of 0.6 episodes of recurrent AOM per child-year children treated with Amoxicillin and a rate of 1.02 in their TT group (P = 0.001).^91^

El-Sayed found no difference in the treatment outcomes of children treated with trimethoprim/sulfamethoxazole compared to children treated with TT (P = 0.37).^92^

##### TT Versus TT and Adenoidectomy

An RCT by Mattila 2003 found no difference in cumulative hazard of recurrent AOM or in efficacy, defined as one minus the adjusted relative risk in randomized and nonrandomized comparisons of children who underwent TT with adenoidectomy compared with TT alone.^93^

In the Kujala 2012 study, there was no significant difference in the TT with adenoidectomy group compared to the TT only group in the number of failures (absolute difference −5%, 95% CI −16 to 6, P = 0.37), in the time to failure (P = 0.29) or to the first AOM (P = 0.6), or in the proportion of children with no AOM episodes (absolute difference 1%, CI −13 to 15, P =1.0).^95^

A subsequent 2005 RCT, which enrolled 217 children, 162 of whom had recurrent AOM, again found no differences in the mean number of otitis media episodes overall or in the subgroup of children with recurrent AOM at enrollment.^94^

##### Quality of Life Outcomes

Although Kujala 2012 found that insertion of TT tubes, without or without adenoidectomy, significantly reduced the risk of recurrent AOM, a subsequent publication from the same trial examining quality of life outcomes at study entry, 4 months, and 12 months (assessed using the Otitis Media-6 questionnaire) found no differences in overall ear-related quality of life between surgically treated groups and no surgery groups, nor did they find any differences in the subscales of caregiver concern, emotional distress, physical suffering, activity limitations, hearing loss, or speech impairment.^96^

#### Nonrandomized Comparative Studies

A cross sectional study by Grindler et al. reported both disease specific quality of life outcomes utilizing OM-6 score, and health related quality of life using the PedsWL Infant Impact Module in 1208 patients. The OM-6 score was higher (reflecting worse otitis specific quality of life) in children in otolaryngology practices who had been recommended to undergo TT placement than in children with prior TT placement.^8^

### Key Question 2a

What factors (such as age, age of onset, number of recurrences, presence of persistent middle ear effusion, comorbidities, sociodemographic risk factors, history of complications of acute otitis media, antibiotic allergy or intolerance) predict which children are likely to benefit from the intervention?

There are no prospective planned comparisons evaluating whether the presence of middle ear effusion (at time of surgical evaluation) modifies the effectiveness of TT placement for recurrent AOM. Gonzalez 1986 report a retrospective subgroup comparison based on the presence or absence of middle ear effusion at initial evaluation and conclude that the attack rate, as well as the number of patients who had no further bouts of AOM, was significantly better (p < 0.05) in those children without middle ear effusion. However, this group consisted of only 22 patients.^90^ Two studies specifically excluded patients with middle ear effusion at time of surgical evaluation.^91,95^

Casselbrant 1992 analyzed data with a multivariable Poisson model and concluded that TT reduced the number of episodes of AOM/otorrhea only in those subjects whose episodes of AOM occurred year-round. In their model, younger age and white race were significantly associated with higher rates of recurrent AOM, but treatment by age and treatment by race interactions were not found.^91^

## Key Question 3

What adverse events, surgical complications, and sequelae are associated with inserting tympanostomy tubes (TT) in children with either chronic otitis media with effusion or recurrent acute otitis media?

We extracted descriptive data on the occurrence of 11 adverse events from 85 prospective surgical studies enrolling at least 50 subjects (including arms of RCTs or NRCSs with 50 or more patients) and population-based retrospective single-group studies (registry studies) with at least 1000 subjects. Adverse events were also extracted from a treatment arm (if it included at least 50 patients) 10 RCTs and NRCSs identified for KQs 1 and 2. The adverse events extracted included perioperative complications, otorrhea, tube blockage, granulation tissue formation, premature extrusion, displacement of the TT into the middle ear space, persistent perforation, myringosclerosis, presence of atrophy, atelectasis or retraction, cholesteatoma, and long-term hearing loss. We did not consider other adverse events, such as antibiotic resistance, gastrointestinal side effects of antibiotics, or pain related to ear drops.

Table 11 provides a highly summarized summary of number of publications (some publications reported several cohorts summarized separately) that reported numbers of patients (or ears) for each adverse event. We do not estimate the frequency of adverse events in a population, rather a descriptive summary of observed median and range of estimates in studies.

Table 11 Adverse events associated with TT placement

Adverse Event | N publications | Patients: Median Percent [25%, 75th%] | Ears: Median Percent (25%, 75th%)
Perioperative Complications | 4^95, 97–99^ | NA | NA
Otorrhea | 39^17, 36, 42, 88, 97, 100–133^ | 20.6 [13.1, 47.3] | 10.4 [9.1, 28.2]
Tube Blockage | 18^97, 99, 103, 123, 127, 130–142^ | 9.0 [ 2.6, 10.7] | 4.0 [2.8, 17.1]
Granulation Tissue | 12^36, 106, 109, 110, 118, 127, 130–132, 134, 136, 143^ | 3.3 [ 2.9, 5.7] | 3.9 [1.8, 5.7]
Premature Extrusion | 18^112, 115, 118, 123, 125, 127, 129, 130, 136, 140, 144–151^ | 13.3 [ 7.1,47.9] | 4.1 [1.6, 14.0]
TT Displacement into middle ear | 8^127, 130, 134, 135, 143, 145, 152, 153^ | NA | 0.8 [0.7, 0.9]
Persistent Perforation | 48^36, 44, 52, 61, 74, 91, 100, 101, 103, 105, 107, 108, 110, 116^_–_^118, 121, 122, 127, 129–131, 133–136, 138, 143–145, 147, 148, 150, 152–166^ | 2.7 [1.8, 6.7] | 2.9 [ 2.0, 5.3 ]
Myringosclerosis | 22^36, 52, 61, 74, 122, 130–132, 134, 135, 148, 150, 152, 155, 157, 163, 167–172^ | 33.5 [5.0, 38.0] | 17.1 [6.8, 43.9]
Atrophy, Atelectasis or Retraction | 22^52, 61, 100, 121, 122, 130, 131, 133, 136, 148, 149, 153, 155, 157, 161, 163, 166, 168, 170, 173–175^ | 13.9 [7.5, 25.9] | 14.4 [ 5.0, 32.8]
Cholesteatoma | 24^88, 100, 108, 115, 122, 127, 131–134, 136, 143, 145–147, 155, 162, 167, 168, 173, 176–179^ | 0.9 [0.2, 1.8] | 0.7 [ 0.1, 3.2 ]
Hearing Loss | 10^99, 112, 114, 123, 129, 135, 148, 156, 167, 170^ | 8.0 [ 1.2, 19.2] | NA

NA: Not calculated when number of patients (ears) < 5.

TT=Tympanostomy Tubes

See Appendix H for an evidence map and study specific details. In general, the study specific definitions of adverse events were poorly reported and/or highly variable between studies. Not all cohorts followed all patients until extrusion of the tube, nor was followup complete in all studies.

Perioperative adverse events were described in 4 studies.^95, 97–99^ Of these, three studies^95, 97, 99^ reported surgical adverse events including ear canal abrasion, tympanic membrane tear and hemorrhage. The 2002 report by Hoffman^98^, reported perioperative events in 0.81% of 3198 patients. Isaacson, 2008 report no operative deaths in a prospective series of 10,000 tube insertions.^99^

Otorrhea was reported in 39 publications. Otorrhea is particularly complex to characterize, as it may differ with respect to frequency, duration, volume, character (e.g. purulent vs. clear) and associated signs and symptoms (such as pain, fever or odor). Studies had different durations of followup, and used multiple categorical definitions (e.g. at least one episode or more than 3 episodes).

Tube blockage was reported in 18 publications. The median percentage of patients with TT blockage was 6.7% across studies. Duration of followup ranged from 2 weeks postoperative to time of extrusion or removal. In most cases, it was not possible to determine if occlusion was temporary or permanent.

Granulation Tissue was reported as an adverse event in 12 publications. In most cases studies did not report the clinical impact or symptoms associated with this finding.

Premature Extrusion was reported in 18 studies. Studies often either did not define what time interval was considered premature. The interquartile range for percent of premature extrusion was wide, likely due in large part to highly variable definitions.

TT displacement into the middle ear, reported in 9 studies.

Persistent Perforation of the tympanic membrane after TT extrusion or removal was reported in 49 publications in a median of 2.7 percent of patients. The majority of studies did not report the duration, associated symptoms or whether these were surgically repaired.

Myringosclerosis, reported in 22 studies, and Atrophy, Atelectasis or Retraction (also reported in 22 studies) were common, but definitions were variable and often poorly described.

Cholesteatoma was reported in 25 studies and Hearing Loss in 10 studies.

## Key Question 4

Do water precautions reduce the incidence of tympanostomy tube otorrhea or affect quality of life?

### Description of Comparative Studies

We identified 11 publications which reported 2 RCTs^180, 181^ and 9 NRCSs^182–190^

#### RCTs

The RCTs are briefly summarized in Table 12. In the Goldstein 2005 study^180^ children in the “ear plugs group” were instructed to wear ear plugs when bathing, showering and washing hair. The “no precautions” group was allowed to swim or bathe without ear plugs. Parents were given a calendar to record all swimming and bathing activities. A subgroup of children with 125 or more instances of water exposure was reported. The Parker 1994^181^ RCT assigned children to a nonswimming group and a swimming group (without earplugs or other precautions).

Table 12 RCTs: Water precautions — one or more episodes of otorrhea

Study PMID Enrollment dates Country (Design) | Followup time | Intervention | Population | n/N (%) | Odds ratio (95% CI)
Goldstein 2005 15689760 7/1996–6/1999 U.S.^180^ | 1 year | Ear plugs | All Participants | 42/90 (46.7) | 0.68 (0.37 – 1.25)
Goldstein 2005 15689760 7/1996–6/1999 U.S.^180^ | 1 year | No precautions | All Participants | 46/82 (56.1) | [reference]
Goldstein 2005 15689760 7/1996–6/1999 U.S.^180^ | 1 year | Ear plugs | Children who each had ≥ 125 instances of water exposure | 29/39 (74.3) | 2.69 (0.95 – 7.64)
Goldstein 2005 15689760 7/1996–6/1999 U.S.^180^ | 1 year | No precautions | Children who each had ≥ 125 instances of water exposure | 14/27 (51.8) | [reference]
Parker 1994 8024107 12/1989–2/1991 U.S.^181^ | 1 year | Nonswimming | All Participants | 18/30 (60.0) | 0.71 (0.29 – 1.76)
Parker 1994 8024107 12/1989–2/1991 U.S.^181^ | 1 year | Ear plugs^†^ | All Participants | 13/15 (86.7) | 3.10 (0.64 – 15.04)
Parker 1994 8024107 12/1989–2/1991 U.S.^181^ | 1 year | No precautions | All Participants | 42/62 (67.7) | [reference]

† Randomized to the nonswimming group, but self-selected to swim using ear precautions (e.g., ear plugs, wax, cotton with petroleum jelly) – considered an nonrandomized comparative studyin the meta-analysis.

RCT=Randomized Control Trial; CI= Confidence Interval

#### NRCS

In two of the 9 NRCSs, otorrhea was reported only as episodes-per-ear (not per patient) in children who chose to swim versus those who chose not to swim. Both studies report similar proportions of ears with otorrhea in swimmers and nonswimmers (6.4% vs. 6.9%^188^) and 23% vs. 18%^190^) and are not considered further.

The remaining 7 NRCSs (shown in Table 13) compared two alternate forms of water precaution (ear plugs or prohibition of swimming) versus no precautions (children allowed to swim without ear protection). Children permitted to swim were often instructed to avoid of high risk activities (e.g., diving, underwater swimming). See Table 13 and Appendixes C–E for study details.

Table 13 NRCSs: Water precautions—one or moreepisodes of otorrhea

Becker 1987 3586818 4/1985–9/1985 U.S. (NRCS)^182^ | ≥ 2 months | Nonswimming | All Participants | 9/30 (30) | 2.31 (0.67 – 7.94)
Becker 1987 3586818 4/1985–9/1985 U.S. (NRCS)^182^ | ≥ 2 months | Ear plugs | All Participants | 7/23 (30.4) | 2.36 (0.64 – 8.70)
Becker 1987 3586818 4/1985–9/1985 U.S. (NRCS)^182^ | ≥ 2 months | No precautions | All Participants | 5/32(15.6) | [reference]
Cohen 1994 8289048 1990–1992 Israel^183^ | 2.5 years | Nonswimming | All Participants | 2/20 (10.0) | 1.11 (0.14 – 8.72)
Cohen 1994 8289048 1990–1992 Israel^183^ | 2.5 years | No precautions | All Participants | 2/22 ( 9.1) | [reference]
el Silimy 1986 3780019 [No dates] UK^184^ | 6 months | Nonswimming | All Participants | 14/41 (34.1) | 2.07 (0.78 – 5.50)
el Silimy 1986 3780019 [No dates] UK^184^ | 6 months | No precautions | All Participants | 9/45 (20.0) | [reference]
Francois1992 1485779 [No dates] France ^185^ | 3–4 months | Nonswimming | All Participants | 21/68 (30.1) | 2.89 (1.43 – 5.86)
Francois1992 1485779 [No dates] France ^185^ | 3–4 months | No precautions | All Participants | 19/142 (13.3) | [reference]
Kaufmann 1999 10546304 1/1996–1/1997 Switzerland^186^ | ≥ 3 months | Ear plugs | All Participants | 4/16 (25.0) | 0.59 (0.16 – 2.11)
Kaufmann 1999 10546304 1/1996–1/1997 Switzerland^186^ | ≥ 3 months | No precautions | All Participants | 17/47 (36.2) | [reference]
Salata 1996 8607955 [No dates] U.S. ^187^ | 1.5 years | Nonswimming | All Participants | 7/116 (6.0) | 0.34 ( 0.14 – 0.82)
Salata 1996 8607955 [No dates] U.S. ^187^ | 1.5 years | Ear plugs | All Participants | 12/44 (27.3) | 1.92 (0.88 – 4.42)
Salata 1996 8607955 [No dates] U.S. ^187^ | 1.5 years | Ear drops | All Participants | 23/101 (22.8) | 1.55 (0.81 – 2.98)
Salata 1996 8607955 [No dates] U.S. ^187^ | 1.5 years | No precautions | All Participants | 22/138 (15.9) | [reference]
Smelt 1984 653821 [No dates] UK^189^ | ≥ 2 months | Nonswimming | All Participants | 6/40 (15.0) | 2.35 (0.55 – 10.12)
Smelt 1984 653821 [No dates] UK^189^ | ≥ 2 months | No precautions | All Participants | 3/43 ( 7.0) | [reference]

95% Confidence intervals that exclude a null effect are shown in bold

### Risk of Bias

The Goldstein 2005 RCT was rated high risk of bias for allocation concealment and blinding of participants (investigators were blinded), but otherwise risk of bias was low or unclear. The Parker 1994 RCT was rated as high risk of bias for random sequence generation (use of social security numbers), blinding of participants, incomplete outcome data (only 105 of 212 available for followup), lack of an intention-to-treat analysis. (15/45 assigned to nonswimming group self-selected to swim and are analyzed as an NRCS), and compliance bias. All of the NRCSs had high risk of selection biases since patient assignment was based on parent and/or patient choice.

### Outcomes

Goldstein 2005 reported a slightly lower adjusted rate of otorrhea randomly assigned to use ear plugs (0.07 episodes/month in intervention group versus 0.10 episodes/month in the control group, P=0.05).

The summary odds ratio reported by Goldstein was 0.68 (95% CI 0.37 to 1.25). Parker 1994 reported a summary odds ratio of 0.71 (95% CI 0.29 to 1.76)

Figure 12 summarizes our random effects meta-analysis of NRCSs, with separate summary estimates for each of the two forms of water protection (ear plugs and avoidance of swimming). The summary odds ratio comparing ear plugs versus no precautions of having one or more episodes of otorrhea was 1.7 (95% CI 0.95 to 3.06). The odds ratio for nonswimming compared to no precautions was 1.52 (95% CI 0.71 to 3.25). It is notable that event rates in the RCTs are generally higher in both control and intervention arms, compared with lower event rates in the NRCSs, possibly reflecting better ascertainment of episodes of otorrhea in the RCTs.

Figure 12 NRCSs only, children with one or more episodes of otorrhea

OR = Odds ratio (values greater than 1 favor ‘no precautions’ arms; values less than 1 favor the intervention (ear plugs or nonswimming); NRCS=Nonrandomized Comparative Study; CI= Confidence Interval

Illustrates the effectiveness of nonrandomized comparative studies of ear plugs or nonswimming compared to no precautions. The summary odds ratio for the comparison of ear plugs was 1.7, with a 95 percent confidence interval ranging from 0.95 to 3.06. For the nonswimming vs. no precautions, the summary odds ratio was 1.52 (95% confidence interval 0.71 to 3.25).

Overall, aside from the small reduction in mean number of episodes of otorrhea found in Goldstein 2005, the available evidence suggests that ear plugs or avoidance of swimming does not reduce the risk of swimming-related otorrhea.

## Key Question 5

In children with tympanostomy tube otorrhea, what is the comparative effectiveness of topical antibiotic drops versus systemic antibiotics or watchful waiting on duration of otorrhea, quality of life, or need for tube removal?

We identified 14 publications,^19, 139, 142, 190–200^ representing 11 studies (10 RCTs and 1 NRCS), with a total of 1811 patients analyzed (1405 in RCTs and 406 in the NRCS) that assessed the effectiveness of various interventions to treat TT otorrhea. The results and arm details of these studies are given in Table 14. For full study details, see Appendixes C–E.

Table 14 Effectiveness of various interventions to treat TT otorrhea

Study Year, PMID, Enrollment Period, Country | Intervention Details | Responders | N
Dohar 1999 10326811 U.S.^194^ | ofloxacin eardrops | 119 | 141
| unclear - historical practice | 140 | 218
| unclear - current practice | 33 | 47
Dohar 2006 16880248 5/2003–5/2004 U.S. & Finland^142^ NRCS | ciprofloxacin/dexamethasone ear drops | 33 | 39
| oral amoxicillin–clavulanate | 24 | 41
Goldblatt 1998 10190709 U.S. | ofloxacin eardrops | 107 | 140
| oral amoxicillin–clavulanate | 101 | 146
Granath 2008 18565598 -2/1998–12/2002 Sweden^197^ | hydrocortisone + oxytetracycline + polymyxine | 12 | 15
| hydrocortisone + oxytetracycline + polymyxine & oral amoxacillin +/− clavulinate | 19 | 22
Heslop 2010 20979100 5/2003–5/2007 Chile^198^ | ciprofloxacin ear drops | 17 | 22
| oral amoxicillin | 6 | 20
| saline rinse | 12 | 26
Roland 2003 14660913 3/2000–2/2001 U.S. ^196^ | ciprofloxacin/dexamethasone ear drops | 72 | 87
| ciprofloxacin ear drops | 72 | 80
Roland 2004 14702493 U.S.^139, 191, 201^ | ciprofloxacin/dexamethasone ear drops | 174 | 207
| ofloxacin eardrops | 153 | 216
Ruohola 1999 10190921 03/1996–05/1997 Denmark^193^ | oral amoxicillin & oral prednisolone | 22 | 23
| oral amoxicillin | 24 | 27
Ruohola 2003 12728089 09/1998–06/1999 Finland ^195^ | oral amoxicillin–clavulanate | 28 | 34
| oral placebo | 13 | 32
Strachan 2000 10865480 UK^202^ | neomycin/polymyxin B/hydrocortisone (drops) | 24 | 29
| neomycin/dexamethasone | 19 | 29
van Dongen 2014 24552319 6/2009–5/2012 Netherlands ^19, 199^ | hydrocortisone–bacitracin–colistin eardrops | 72 | 76
| oral amoxicillin–clavulanate | 43 | 77
| initial observation | 34 | 75

TT= Tympanostomy Tubes; NRCS= Nonrandomized Comparative Study

### Risk of Bias

Risk of bias was low for random sequence generation and allocation concealment. However, 8 of 11 studies had high risk of bias due to open label design, which precluded blinding of personnel and care providers.

The studies reported multiple comparisons, summarized in Figure 13, including oral antibiotics (amoxicillin and amoxicillin/clavulinate), various antibiotic drops, and various antibiotic-glucocorticoid drops, oral corticosteroids, and combinations. Treatment arms grouped in the watchful waiting/placebo category included watchful waiting,^199^ oral placebo^195^ and topical saline wash.^198^

Figure 13 Network of treatment comparisons (RCTs)

Two studies are not shown in network graph: 1) Dohar 1999 (undefined comparators. 2) Roland 2004 (comparison of two topical antibiotic-glucocorticoid treatments). Studies with the treatment arms show as dotted lines do not contribute indirect information, and are excluded from the network meta-analysis. The network plot consists of nodes representing the interventions being compared and edges representing the available direct comparisons. The number of studies that include each comparison is indicated next to each edge (connecting lines with thickness proportional to this number).

PO= Oral; RCT= Randomized Control Trial

A topology map of the network of available comparisons used for meta-analysis of different interventions for treatment of Tympanostomy tube otorrhea. Six classes of intervention are displayed; Watchful waiting or Placebo, Oral antibiotic, topical antibiotic, topical antibiotic-glucocorticoid, oral antibiotic and oral glucocorticoid and topical antibiotic-glucocorticoid and oral antibiotic. Of the 15 possible pairwise contrasts, 8 are covered by direct comparisons. Three studies provide direct comparisons between oral antibiotics and Watchful waiting or Placebo. Two studies contrast oral antibiotics with topical antibiotic treatments and two studies contrast topical antibiotic-glucocorticoid drops with oral antibiotics. A single study directly compares Watchful waiting or placebo with topical antibiotics and with topical antibiotic-glucocorticoid treatments.

### Outcomes

#### Clinical Cure

Eleven studies reported the number of clinically cured patients in each arm, often at multiple timepoints. All studies reported additional intermediate outcomes (e.g., cessation, improvement, or duration of otorrhea). For the meta-analysis, we chose the time designated by each of these studies as the test of cure (range 7 to 20 days after initiation of treatment).

Four studies were excluded from the network meta-analysis. In two studies, this related to the intervention. Dohar 1999^194^ NRCS reported clinical cure in 84.6 percent of 143 patients treated with topical ofloxacin in compared to a 64.2 percent in a historical practice group (n=218) and a 70 percent clinical cure rate in a concurrent practice group (n=47). However, the specific treatments used in the historical practice group and concurrent practice group were not reported. The second excluded study, Strachan 2000 ^202^, compared an antibiotic-glucocorticoid topical drop containing neomycin sulfate, polymyxin B sulfate and hydrocortisone with a topical spray formulation containing neomycin sulfate and dexamethasone. They concluded that topical treatment with a nonpressurized ear spray was easier to use and caused less discomfort than ear drops. However, they found no overall difference in number of patients cured..

Two studies^193, 197^ compared dual interventions (i.e. topical antibiotic-glucocorticoid and oral antibiotic, oral antibiotic and oral glucocorticoid) and were not included in the network meta-analysis, as they contributed no indirect evidence for the comparisons of primary interest.

The pairwise comparative effects of interventions are shown in Table 15. Treatment strategies that include topical antibiotic-glucocorticoid drops predominate over oral antibiotics and watchful waiting or placebo. Treatment strategies that include topical antibiotic-glucocorticoid drops predominate over oral antibiotics and watchful waiting or placebo.

Table 15 Network meta-analysis of interventions for otorrhea

Topical Antibiotic-Glucocorticoid | −0.49 (−2.03, 1.08) | −1.68 (−3.32, −0.16) | −2.46 (−4.4, −0.6)
0.49 (−1.08, 2.03) | Topical Antibiotic | −1.19 (−2.82, 0.31) | −1.97 (−3.94, −0.14)
1.68 (0.16, 3.32) | 1.19 (−0.31, 2.82) | Oral Antibiotic | −0.78 (−2.33, 0.78)
2.46 (0.6, 4.4) | 1.97 (0.14, 3.94) | 0.78 (−0.78, 2.33) | WW or Placebo

Ab-GC: Antibiotic-glucocorticoid. Differences in Log Odds Ratios with 95% Credible Intervals for clinical cure of otorrhea among the 4 treatments in Figure 13. Each cell contains the odds ratio for the comparison of the intervention in the corresponding row versus the intervention in the corresponding column.

WW= Watchful Waiting

Table 16 lists the probabilities derived from the network meta-analysis that a particular intervention is ranks first to fourth most effective. The probability rankings suggest: 1) treatment strategies that include topical antibiotic drops predominate treatment with oral antibiotics and 2) all active treatments are more effective than watchful waiting/placebo.

Table 16 Probabilities (%) that an intervention ranks as the i-th most effective with respect to clinical resolution of otorrhea

Intervention | 1st | 2nd | 3rd | 4th
Topical Antibiotic-Glucocorticoid | 77 | 21 | 1 | 0
Topical Antibiotic | 22 | 73 | 5 | 1
Oral antibiotic | 1 | 5 | 83 | 12
Watchful waiting/placebo | 0 | 1 | 12 | 87

Figure 14 illustrates the relative effectiveness of each intervention compared to watchful waiting or placebo. Treatment with either topical antibiotic-glucocorticoid or topical antibiotic are superior to watchful waiting/placebo.

Figure 14 Relative effectiveness of various interventions compared to watchful waiting or placebo

CrI= Credibility Interval; OR= Odds Ratio

Illustrates the combined direct and indirect estimates from the network meta-analysis of the summary odds ratios for the various interventions compared to Watchful waiting or Placebo. The summary odds ratio for topical antibiotic-glucocorticoid drops is 12.0 (95 percent credible interval: 1.9 to 83). The odds ratio for topical antibiotic is 7.2 (95% credible interval: 1.2 to 50.0). The odds ratio for oral antibiotics is 2.2 (95% credible interval: 0.47 to 10).

Figure 15 illustrates the relative effectiveness of each intervention compared to oral antibiotics. Treatment with topical antibiotic-glucocorticoid is superior to oral antibiotics. The relative effectiveness of topical antibiotic (without glucocorticoid) compared to oral antibiotics suggests greater effectiveness, but the credible interval includes one.

Figure 15 Relative effectiveness of interventions compared to oral antibiotics

CrI= Credibility Interval; OR= Odds Ratio

Illustrates the combined direct and indirect estimates from the network meta-analysis of the summary odds ratios for the various interventions compared to oral antibiotics. The summary odds ratio for topical antibiotic-glucocorticoid drops is 5.3 (95 percent credible interval: 1.2 to 28.0). The odds ratio for topical antibiotic is 3.3 (95% credible interval: 0.74 to 17.0). The odds ratio for Watchful waiting or placebo is 0.45 (95% credible interval: 0.10 to 2.1).

#### Quality of Life

A single study (summarized in Table 17) reports quality of life outcomes related to our comparative effectiveness questions. Van Dongen 2014 evaluated quality of life in 230 children with otorrhea who received either watchful waiting, oral antibiotics, or antibiotic-glucocorticoid drops for 7 days.^199^ At baseline, the generic and disease-specific health-related quality-of-life scores indicated good quality of life and were similar across the groups. At 2 weeks of followup, the change in the generic health-related quality-of-life scores did not differ significantly among the study groups. The changes in the disease-specific health-related quality-of-life scores at 2 weeks were small but consistently favored ear drops. The minimal clinically important difference for the generic Quality of Life instrument used in Van Dongen 2014 (CHQ-PF28) is not clear. Using as reference the range of the score, which is between 1 and 35 with higher values implying better quality of life, the 95% confidence intervals for the within group differences are judged to be large; thus it is possible that the Van Dongen 2014 trial results cannot exclude clinically important differences.

Table 17 Quality of life outcomes

Author | Outcome | Timepoint | Arm | N analyzed | Baseline median (range) | Within Arm Median Difference (range) | P value
van Dongen 2014 24552319 25896832 6/2009–5/2012 Netherlands^19, 199, 200^ | Quality of life (CHQ-PF28, lower scores indicate better QOL) | 2 weeks | watchful waiting | 77 | 14 (5, 33) | 0.5 (−15, 26) | NS
van Dongen 2014 24552319 25896832 6/2009–5/2012 Netherlands^19, 199, 200^ | Quality of life (CHQ-PF28, lower scores indicate better QOL) | 2 weeks | oral antibiotic | 77 | 15.5 (6, 28) | 1 (−11, 18) | NS
van Dongen 2014 24552319 25896832 6/2009–5/2012 Netherlands^19, 199, 200^ | Quality of life (CHQ-PF28, lower scores indicate better QOL) | 2 weeks | antibiotic-glucocorticoid drops | 76 | 15.5 (6, 29) | −1 (−14, 11) | NS

QoL= Quality of Life, NS= not signficant