# References

1 Rosenfeld RM, Schwartz SR, Pynnonen MA, . Clinical practice guideline: Tympanostomy tubes in children. Otolaryngol Head Neck Surg 2013 Jul;149(1 Suppl):S1–35. doi: 10.1177/0194599813487302. PMID: 23818543.23818543
2 Schilder AG, Chonmaitree T, Cripps AW, . Otitis media. Nat Rev Dis Primers 2016;2:16063. doi: 10.1038/nrdp.2016.63. PMID: 27604644.27604644
3 Boonacker CW, Rovers MM, Browning GG, . Adenoidectomy with or without grommets for children with otitis media: an individual patient data meta-analysis. Health Technol Assess 2014 Jan;18(5):1–118. doi: 10.3310/hta18050. PMID: 24438691.24438691
4 Rettig E, Tunkel DE. Contemporary concepts in management of acute otitis media in children. Otolaryngol Clin North Am 2014 Oct;47(5):651–72. doi: 10.1016/j.otc.2014.06.006. PMID: 25213276.25213276
5 Cullen KA, Hall MJ, Golosinskiy A. Ambulatory surgery in the United States, 2006. Natl Health Stat Report 2009 Jan 28(11):1–25. PMID: 19294964.19294964
6 Proceedings from the National Summit on Overuse. 2012. The Joint Commission. https://www.jointcommission.org/assets/1/6/National_Summit_Overuse.pdf. Accessed December 21, 2016.
7 Kleinman LC, Kosecoff J, Dubois RW, . The medical appropriateness of tympanostomy tubes proposed for children younger than 16 years in the United States. JAMA 1994 Apr 27;271(16):1250–5. PMID: 7710469.7710469
8 Grindler DJ, Blank SJ, Schulz KA, . Impact of Otitis Media Severity on Children’s Quality of Life. Otolaryngol Head Neck Surg 2014 Mar 13;151(2):333–40. doi: 10.1177/0194599814525576. PMID: 24627408.24627408
9 Hoffman HJ, Daly KA, Bainbridge KE, . Panel 1: Epidemiology, natural history, and risk factors. Otolaryngol Head Neck Surg 2013 Apr;148(4 Suppl):E1–E25. doi: 10.1177/0194599812460984. PMID: 23536527.23536527
10 Croft P, Altman DG, Deeks JJ, . The science of clinical practice: disease diagnosis or patient prognosis? Evidence about “what is likely to happen” should shape clinical practice. BMC Med 2015;13:20. doi: 10.1186/s12916-014-0265-4. PMID: 25637245.25637245
11 Paulson LM, Weaver TS, Macarthur CJ. Outcomes of tympanostomy tube placement in children with Down syndrome--a retrospective review. Int J Pediatr Otorhinolaryngol 2014 Feb;78(2):223–6. doi: 10.1016/j.ijporl.2013.10.062. PMID: 24321289.24321289
12 Kuo CL, Tsao YH, Cheng HM, . Grommets for otitis media with effusion in children with cleft palate: a systematic review. Pediatrics 2014 Nov;134(5):983–94. doi: 10.1542/peds.2014-0323. PMID: 25287451.25287451
13 Ackerman S, Reilly B, Bernier R. Tympanostomy tube placement in children with autism. J Dev Behav Pediatr 2012 Apr;33(3):252–8. doi: 10.1097/DBP.0b013e31824b9f57. PMID: 22343482.22343482
14 Rosenfeld RM, Kay D. Natural history of untreated otitis media. Laryngoscope 2003 Oct;113(10):1645–57. PMID: 14520089.14520089
15 Lieberthal AS, Carroll AE, Chonmaitree T, . The diagnosis and management of acute otitis media. Pediatrics 2013 Mar;131(3):e964–99. doi: 10.1542/peds.2012–3488. PMID: 23439909.23439909
16 Tsao GJ, Goode RL. Are water precautions necessary after tympanostomy tube placement? Laryngoscope. 2014 Jul;124(7):1513–4. doi: 10.1002/lary.24473. PMID: 24142762.24142762
17 van Dongen TM, van der Heijden GJ, Freling HG, . Parent-reported otorrhea in children with tympanostomy tubes: incidence and predictors. PLoS One 2013;8(7):e69062. doi: 10.1371/journal.pone.0069062. PMID: 23874870.23874870
18 Casselbrant ML, Kaleida PH, Rockette HE, . In reference to What is the role of tympanostomy tubes in the treatment of recurrent acute otitis media? Laryngoscope. 2013 Dec;123(12):E127. doi: 10.1002/lary.24142. PMID: 24105683.24105683
19 van Dongen TM, Schilder AG, Venekamp RP, . Cost-effectiveness of treatment of acute otorrhea in children with tympanostomy tubes. Pediatrics 2015 May;135(5):e1182–9. doi: 10.1542/peds.2014-3141. PMID: 25896832.25896832
20 Wang JC, Hamood AN, Saadeh C, . Strategies to prevent biofilm-based tympanostomy tube infections. Int J Pediatr Otorhinolaryngol 2014 Sep;78(9):1433–8. doi: 10.1016/j.ijporl.2014.05.025. PMID: 25060938.25060938
21 Methods Guide for Effectiveness and Comparative Effectiveness Reviews. AHRQ Publication No. 10(12)-EHC063-EF. Rockville, MD: Agency for Healthcare Research and Quality; 2012.
22 Williams K, Thomson D, Seto I, . Standard 6: age groups for pediatric trials. Pediatrics 2012 Jun;129(Suppl 3):S153–60. doi: 10.1542/peds.2012-0055I. PMID: 22661762.22661762
23 Rosenfeld RM, Schwartz SR, Pynnonen MA, . Clinical practice guideline: tympanostomy tubes in children--executive summary. Otolaryngol Head Neck Surg 2013 Jul;149(1):8–16. doi: 10.1177/0194599813490141. PMID: 23818537.23818537
24 Higgins JP, Altman DG, Gotzsche PC, . The Cochrane Collaboration’s tool for assessing risk of bias in randomised trials. BMJ 2011;343:d5928. doi: 10.1136/bmj.d5928. PMID: 22008217.22008217
25 Wells GA SB, O’Connell D, Peterson J, Welch V, Losos M, Tugwell P. The Newcastle-Ottawa Scale (NOS) for assessing the quality of nonrandomised studies in meta-analyses.
26 Normand SL. Meta-analysis: formulating, evaluating, combining, and reporting. Stat Med 1999 Feb 15;18(3):321–59. PMID: 10070677.10070677
27 Team RC. R: A Language and Environment for Statistical Computing. Vienna, Austria: R Foundation for Statistical Computing; 2016.
28 Viechtbauer W. Conducting meta-analyses in R with the metafor package. Journal of Statistical Software 2010;36(3):1–48.
29 van Valkenhoef G, Kuiper J. gemtc: Network Meta-Analysis Using Bayesian Methods. 2016.
30 van Valkenhoef G, Lu G, de Brock B, . Automating network meta-analysis. Res Synth Methods 2012 December;3(4):285–99.26053422
31 JAGS: A program for analysis of Bayesian graphical models using Gibbs sampling. Proceedings of the 3rd International Workshop on Distributed Statistical Computing ({DSC} 2003), March 20–22, Vienna, Austria. Plummer_undated-af.
32 Welton NJ, AJ S, Cooper N, . Evidence Synthesis for Decision Making in Healthcare: Wiley; 2012.
33 Dias S, Welton N, Caldwell D, . Checking consistency in mixed treatment comparison meta-analysis. Statistics in medicine 2010;29(7–8):932–44.20213715
34 van Valkenhoef G, Dias S, Ades AE, . Automated generation of node-splitting models for assessment of inconsistency in network meta-analysis. Res Synth Methods 2016 March;7(1):80–93.26461181
35 Berkman ND, Lohr KN, Ansari M, . AHRQ Methods for Effective Health Care: Grading the Strength of a Body of Evidence When Assessing Health Care Interventions for the Effective Health Care Program of the Agency for Healthcare Research and Quality: An Update. Methods Guide for Effectiveness and Comparative Effectiveness Reviews. Rockville (MD): Agency for Healthcare Research and Quality (US); 2008.
36 Bernard PA, Stenstrom RJ, Feldman W, . Randomized, controlled trial comparing long-term sulfonamide therapy to ventilation tubes for otitis media with effusion. Pediatrics 1991 Aug;88(2):215–22. PMID: 1861917.1861917
37 Casselbrant ML, Mandel EM, Rockette HE, . Adenoidectomy for otitis media with effusion in 2–3-year-old children. Int J Pediatr Otorhinolaryngol 2009 Dec;73(12):1718–24. doi: 10.1016/j.ijporl.2009.09.007. PMID: 19819563.19819563
38 Chaudhuri GR, Bandyopadhyay SN, Basu SK. Role of grommet in otitis media with effusion: A necessity or nuisance? A comparative study. Indian J Otolaryngol Head Neck Surg 2006 Jul;58(3):271–3. doi: 10.1007/bf03050837. PMID: 23120310.23120310
39 D’Eredita R, Shah UK. Contact diode laser myringotomy for medium-duration middle ear ventilation in children. Int J Pediatr Otorhinolaryngol 2006 Jun;70(6):1077–80. doi: 10.1016/j.ijporl.2005.11.003. PMID: 16406076.16406076
40 Hall AJ, Maw AR, Steer CD. Developmental outcomes in early compared with delayed surgery for glue ear up to age 7 years: a randomised controlled trial. Clin Otolaryngol 2009 Feb;34(1):12–20. doi: 10.1111/j.1749-4486.2008.01838.x. PMID: 19260880.19260880
41 Hartman M, Rovers MM, Ingels K, . Economic evaluation of ventilation tubes in otitis media with effusion. Arch Otolaryngol Head Neck Surg 2001 Dec;127(12):1471–6. PMID: 11735817.11735817
42 Ingels K, Rovers MM, van der Wilt GJ, . Ventilation tubes in infants increase the risk of otorrhoea and antibiotic usage. B-ENT 2005;1(4):173–6. PMID: 16429748.16429748
43 Johnston LC, Feldman HM, Paradise JL, . Tympanic membrane abnormalities and hearing levels at the ages of 5 and 6 years in relation to persistent otitis media and tympanostomy tube insertion in the first 3 years of life: a prospective study incorporating a randomized clinical trial. Pediatrics 2004 Jul;114(1):e58–67. PMID: 15231974.15231974
44 Mandel EM, Rockette HE, Bluestone CD, . Myringotomy with and without tympanostomy tubes for chronic otitis media with effusion. Arch Otolaryngol Head Neck Surg 1989 Oct;115(10):1217–24. PMID: 2789777.2789777
45 Mandel EM, Rockette HE, Bluestone CD, . Efficacy of myringotomy with and without tympanostomy tubes for chronic otitis media with effusion. Pediatr Infect Dis J 1992 Apr;11(4):270–7. PMID: 1565550.1565550
46 Maw R, Wilks J, Harvey I, . Early surgery compared with watchful waiting for glue ear and effect on language development in preschool children: a randomised trial. Lancet 1999 Mar 20;353(9157):960–3. doi: 10.1016/s0140-6736(98)05295-7. PMID: 10459904.10459904
47 MRC Multicentre Otitis Media Study Group. The role of ventilation tube status in the hearing levels in children managed for bilateral persistent otitis media with effusion. Clin Otolaryngol Allied Sci 2003 Apr;28(2):146–53. PMID: 12680834.12680834
48 MRC Multicentre Otitis Media Study Group. Speech reception in noise: an indicator of benefit from otitis media with effusion surgery. Clin Otolaryngol Allied Sci 2004 Oct;29(5):497–504. doi: 10.1111/j.1365-2273.2004.00843.x. PMID: 15373863.15373863
49 Nguyen LH, Manoukian JJ, Yoskovitch A, . Adenoidectomy: selection criteria for surgical cases of otitis media. Laryngoscope 2004 May;114(5):863–6. doi: 10.1097/00005537-200405000-00014. PMID: 15126745.15126745
50 Paradise JL, Campbell TF, Dollaghan CA, . Developmental outcomes after early or delayed insertion of tympanostomy tubes. N Engl J Med 2005 Aug 11;353(6):576–86. doi: 10.1056/NEJMoa050406. PMID: 16093466.16093466
51 Paradise JL, Dollaghan CA, Campbell TF, . Otitis media and tympanostomy tube insertion during the first three years of life: developmental outcomes at the age of four years. Pediatrics 2003 Aug;112(2):265–77. PMID: 12897272.12897272
52 Paradise JL, Feldman HM, Campbell TF, . Effect of early or delayed insertion of tympanostomy tubes for persistent otitis media on developmental outcomes at the age of three years. N Engl J Med 2001 Apr 19;344(16):1179–87. doi: 10.1056/nejm200104193441601. PMID: 11309632.11309632
53 Paradise JL, Feldman HM, Campbell TF, . Early versus delayed insertion of tympanostomy tubes for persistent otitis media: developmental outcomes at the age of three years in relation to prerandomization illness patterns and hearing levels. Pediatr Infect Dis J 2003 Apr;22(4):309–14. doi: 10.1097/01.inf.0000059764.77704.55. PMID: 12690269.12690269
54 Paradise JL, Feldman HM, Campbell TF, . Tympanostomy tubes and developmental outcomes at 9 to 11 years of age. N Engl J Med 2007 Jan 18;356(3):248–61. doi: 10.1056/NEJMoa062980. PMID: 17229952.17229952
55 Popova D, Varbanova S, Popov TM. Comparison between myringotomy and tympanostomy tubes in combination with adenoidectomy in 3–7-year-old children with otitis media with effusion. Int J Pediatr Otorhinolaryngol 2010 Jul;74(7):777–80. doi: 10.1016/j.ijporl.2010.03.054. PMID: 20399511.20399511
56 Rach GH, Zielhuis GA, van Baarle PW, . The effect of treatment with ventilating tubes on language development in preschool children with otitis media with effusion. Clin Otolaryngol Allied Sci 1991 Apr;16(2):128–32. PMID: 2070526.2070526
57 Rovers MM, Krabbe PF, Straatman H, . Randomised controlled trial of the effect of ventilation tubes (grommets) on quality of life at age 1–2 years. Arch Dis Child 2001 Jan;84(1):45–9. PMID: 11124783.11124783
58 Rovers MM, Straatman H, Ingels K, . The effect of ventilation tubes on language development in infants with otitis media with effusion: A randomized trial. Pediatrics 2000 Sep;106(3):E42. PMID: 10969126.10969126
59 Rovers MM, Straatman H, Ingels K, . Generalizability of trial results based on randomized versus nonrandomized allocation of OME infants to ventilation tubes or watchful waiting. J Clin Epidemiol 2001 Aug;54(8):789–94. PMID: 11470387.11470387
60 Rovers MM, Straatman H, Ingels K, . The effect of short-term ventilation tubes versus watchful waiting on hearing in young children with persistent otitis media with effusion: a randomized trial. Ear Hear 2001 Jun;22(3):191–9. PMID: 11409855.11409855
61 Velepic M, Starcevic R, Bonifacic M, . The clinical status of the eardrum: an inclusion criterion for the treatment of chronic secretory otitis media in children. Int J Pediatr Otorhinolaryngol 2011 May;75(5):686–90. doi: 10.1016/j.ijporl.2011.02.014. PMID: 21397957.21397957
62 Vlastos IM, Houlakis M, Kandiloros D, . Adenoidectomy plus tympanostomy tube insertion versus adenoidectomy plus myringotomy in children with obstructive sleep apnoea syndrome. J Laryngol Otol 2011 Mar;125(3):274–8. doi: 10.1017/s0022215110002549. PMID: 21205368.21205368
63 Wilks J, Maw R, Peters TJ, . Randomised controlled trial of early surgery versus watchful waiting for glue ear: the effect on behavioural problems in pre-school children. Clin Otolaryngol Allied Sci 2000 Jun;25(3):209–14. PMID: 10944051.10944051
64 Yagi HI. The surgical treatment of secretory otitis media in children. J Laryngol Otol 1977 Mar;91(3):267–70. PMID: 321716.321716
65 Robson AK, Blanshard JD, Jones K, . A conservative approach to the management of otitis media with effusion in cleft palate children. J Laryngol Otol 1992 Sep;106(9):788–92. PMID: 1431515.1431515
66 Hubbard TW, Paradise JL, McWilliams BJ, . Consequences of unremitting middle-ear disease in early life. Otologic, audiologic, and developmental findings in children with cleft palate. N Engl J Med 1985 Jun 13;312(24):1529–34. doi: 10.1056/nejm198506133122401. PMID: 4039792.4039792
67 Forquer BD, Linthicum FH, Jr. Middle ear effusion in children: a report of treatment in 500 cases. West J Med 1982 Nov;137(5):370–4. PMID: 6184891.6184891
68 Marshak G, Neriah ZB. Adenoidectomy versus tympanostomy in chronic secretory otitis media. Ann Otol Rhinol Laryngol Suppl. 1980 May–Jun;89(3 Pt 2):316–8. PMID: 6778336.6778336
69 Peters SA, Grievink EH, van Bon WH, . The effects of early bilateral otitis media with effusion on educational attainment: a prospective cohort study. J Learn Disabil 1994 Feb;27(2):111–21. PMID: 8195687.8195687
70 Grievink EH, Peters SA, van Bon WH, . The effects of early bilateral otitis media with effusion on language ability: a prospective cohort study. J Speech Hear Res 1993 Oct;36(5):1004–12. PMID: 8246466.8246466
71 Schilder AG, Hak E, Straatman H, . Long-term effects of ventilation tubes for persistent otitis media with effusion in children. Clin Otolaryngol Allied Sci 1997 Oct;22(5):423–9. PMID: 9372253.9372253
72 Coyte PC, Croxford R, McIsaac W, . The role of adjuvant adenoidectomy and tonsillectomy in the outcome of the insertion of tympanostomy tubes. N Engl J Med 2001 Apr 19;344(16):1188–95. doi: 10.1056/nejm200104193441602. PMID: 11309633.11309633
73 Xu HF, Xu LR, He Y, . [Treatment of cleft palate with secretory otitis media]. Zhonghua Kou Qiang Yi Xue Za Zhi 2003 Jul;38(4):269–70. PMID: 12930655.12930655
74 de Beer BA, Schilder AG, Ingels K, . Hearing loss in young adults who had ventilation tube insertion in childhood. Ann Otol Rhinol Laryngol 2004 Jun;113(6):438–44. PMID: 15224825.15224825
75 Stenstrom R, Pless IB, Bernard P. Hearing thresholds and tympanic membrane sequelae in children managed medically or surgically for otitis media with effusion. Arch Pediatr Adolesc Med 2005 Dec;159(12):1151–6. doi: 10.1001/archpedi.159.12.1151. PMID: 16330739.16330739
76 Kadhim AL, Spilsbury K, Semmens JB, . Adenoidectomy for middle ear effusion: a study of 50,000 children over 24 years. Laryngoscope 2007 Mar;117(3):427–33. doi: 10.1097/MLG.0b013e31802c938b. PMID: 17279052.17279052
77 Motta G, Esposito E, Motta S, . [Acute recurrent pharyngotonsillitis and otitis media]. Acta Otorhinolaryngol Ital 2006 Oct;26(5 Suppl 84):30–55. PMID: 17465378.17465378
78 Reiter R, Haase S, Brosch S. Repaired cleft palate and ventilation tubes and their associations with cholesteatoma in children and adults. Cleft Palate Craniofac J 2009 Nov;46(6):598–602. doi: 10.1597/08-166.1. PMID: 19929085.19929085
79 Kobayashi H, Sakuma T, Yamada N, . Clinical outcomes of ventilation tube placement in children with cleft palate. Int J Pediatr Otorhinolaryngol 2012 May;76(5):718–21. doi: 10.1016/j.ijporl.2012.02.027. PMID: 22386274.22386274
80 Wolter NE, Dell SD, James AL, . Middle ear ventilation in children with primary ciliary dyskinesia. Int J Pediatr Otorhinolaryngol 2012 Nov;76(11):1565–8. doi: 10.1016/j.ijporl.2012.07.011. PMID: 22883987.22883987
81 Yousaf M, Inayatullah, Khan F. Medical versus surgical management of otitis media with effusion in children. J Ayub Med Coll Abbottabad. 2012 Jan–Mar;24(1):83–5. PMID: 23855103.23855103
82 Youssef TF, Ahmed MR. Laser-assisted myringotomy versus conventional myringotomy with ventilation tube insertion in treatment of otitis media with effusion: Long-term follow-up. Interv Med Appl Sci 2013 Mar;5(1):16–20. doi: 10.1556/imas.5.2013.1.3. PMID: 24265883.24265883
83 Tian L, Chen X, Li G. [The clinical curative effect of the low temperature plasma ablation adenoidectomy and tympanic membrane indwelling catheter in parallel or not used on childhood patients with secretory otitis media]. Lin Chung Er Bi Yan Hou Tou Jing Wai Ke Za Zhi 2015 Mar;29(5):415–7. PMID: 26103659.26103659
84 Li S, Zhang H, Wei Y, . [Clinical comparative study on the treatment characteristics of secretory otitis media between cleft and non-cleft palate patients]. Hua Xi Kou Qiang Yi Xue Za Zhi 2015 Jun;33(3):259–62. PMID: 26281253.26281253
85 Hu S, Patel NA, Shinhar S. Follow-up audiometry after bilateral myringotomy and tympanostomy tube insertion. Int J Pediatr Otorhinolaryngol 2015 Dec;79(12):2068–71. doi: 10.1016/j.ijporl.2015.09.015. PMID: 26429601.26429601
86 Kuscu O, Gunaydin RO, Icen M, . The effect of early routine grommet insertion on management of otitis media with effusion in children with cleft palate. J Craniomaxillofac Surg 2015 Dec;43(10):2112–5. doi: 10.1016/j.jcms.2015.09.008. PMID: 26545930.26545930
87 Niclasen J, Obel C, Homoe P, . Associations between otitis media and child behavioural and learning difficulties: Results from a Danish cohort. Int J Pediatr Otorhinolaryngol 2016 May;84:12–20. doi: 10.1016/j.ijporl.2016.02.017. PMID: 27063746.27063746
88 Gates GA, Avery CA, Prihoda TJ, . Effectiveness of adenoidectomy and tympanostomy tubes in the treatment of chronic otitis media with effusion. N Engl J Med 1987 Dec 3;317(23):1444–51. doi: 10.1056/nejm198712033172305. PMID: 3683478.3683478
89 Gates GA, Wachtendorf C, Hearne EM, . Treatment of chronic otitis media with effusion: results of tympanostomy tubes. Am J Otolaryngol 1985 May–Jun;6(3):249–53. PMID: 4040338.4040338
90 Gonzalez C, Arnold JE, Woody EA, . Prevention of recurrent acute otitis media: chemoprophylaxis versus tympanostomy tubes. Laryngoscope 1986 Dec;96(12):1330–4. PMID: 3537596.3537596
91 Casselbrant ML, Kaleida PH, Rockette HE, . Efficacy of antimicrobial prophylaxis and of tympanostomy tube insertion for prevention of recurrent acute otitis media: results of a randomized clinical trial. Pediatr Infect Dis J 1992 Apr;11(4):278–86. PMID: 1565551.1565551
92 El-Sayed Y. Treatment of recurrent acute otitis media chemoprophylaxis versus ventilation tubes. Australian Journal of Otolaryngology 1996;2(4):352–5.
93 Mattila PS, Joki-Erkkila VP, Kilpi T, . Prevention of otitis media by adenoidectomy in children younger than 2 years. Arch Otolaryngol Head Neck Surg 2003 Feb;129(2):163–8. PMID: 12578443.12578443
94 Hammaren-Malmi S, Saxen H, Tarkkanen J, . Adenoidectomy does not significantly reduce the incidence of otitis media in conjunction with the insertion of tympanostomy tubes in children who are younger than 4 years: a randomized trial. Pediatrics 2005 Jul;116(1):185–9. doi: 10.1542/peds.2004-2253. PMID: 15995051.15995051
95 Kujala T, Alho OP, Luotonen J, . Tympanostomy with and without adenoidectomy for the prevention of recurrences of acute otitis media: a randomized controlled trial. Pediatr Infect Dis J 2012 Jun;31(6):565–9. doi: 10.1097/INF.0b013e318255ddde. PMID: 22466327.22466327
96 Kujala T, Alho OP, Kristo A, . Quality of life after surgery for recurrent otitis media in a randomized controlled trial. Pediatr Infect Dis J 2014 Jul;33(7):715–9. doi: 10.1097/inf.0000000000000265. PMID: 24445832.24445832
97 Brodsky L, Brookhauser P, Chait D, . Office-based insertion of pressure equalization tubes: the role of laser-assisted tympanic membrane fenestration. Laryngoscope 1999 Dec;109(12):2009–14. doi: 10.1097/00005537-199912000-00022. PMID: 10591365.10591365
98 Hoffmann KK, Thompson GK, Burke BL, . Anesthetic complications of tympanostomy tube placement in children. Arch Otolaryngol Head Neck Surg 2002 Sep;128(9):1040–3. PMID: 12220208.12220208
99 Isaacson G. Six Sigma tympanostomy tube insertion: achieving the highest safety levels during residency training. Otolaryngol Head Neck Surg 2008 Sep;139(3):353–7. doi: 10.1016/j.otohns.2008.06.012. PMID: 18722211.18722211
100 Hörmann K, Roehrs M. [Middle-ear findings in young cleft lip and palate children. Comparison of two treatment clinics]. Dtsch Z Mund Kiefer Gesichtschir. 1991 Mar–Apr;15(2):149–52. PMID: 1816937.1816937
101 Suetake M, Kobayashi T, Takasaka T, . Is change in middle ear air volume following ventilation tube insertion a reliable prognostic indicator? Acta Otolaryngol Suppl. 1990;471:73–80. PMID: 2239252.2239252
102 Gates GA, Avery CA, Cooper JC, Jr., . Chronic secretory otitis media: effects of surgical management. Ann Otol Rhinol Laryngol Suppl. 1989 Jan;138:2–32. PMID: 2492178.2492178
103 Weigel MT, Parker MY, Goldsmith MM, . A prospective randomized study of four commonly used tympanostomy tubes. Laryngoscope 1989 Mar;99(3):252–6. doi: 10.1288/00005537-198903000-00003. PMID: 2645490.2645490
104 Gates GA, Avery C, Prihoda TJ, . Delayed onset post-tympanotomy otorrhea. Otolaryngol Head Neck Surg 1988 Feb;98(2):111–5. PMID: 3128752.3128752
105 Debruyne F, Jorissen M, Poelmans J. Otorrhea during transtympanal ventilation. Am J Otol 1988 Jul;9(4):316–7. PMID: 3177616.3177616
106 Tavin ME, Gordon M, Ruben RJ. Hearing results with the use of different tympanostomy tubes: a prospective study. Int J Pediatr Otorhinolaryngol 1988 Feb;15(1):39–50. PMID: 3372141.3372141
107 Debruyne F, Jorissen M, Poelmans J. [Follow-up of trans-tympanum tubes]. Acta Otorhinolaryngol Belg 1986;40(4):666–77. PMID: 3799183.3799183
108 Rothera MP, Grant HR. Long-term ventilation of the middle ear using the Goode T-tube. J Laryngol Otol 1985 Apr;99(4):335–7. PMID: 4040147.4040147
109 Levinson SR, Gill AJ, Teich L. Semipermeable membrane tubes: a prospective study. Otolaryngol Head Neck Surg 1982 Sep–Oct;90(5):622–8. PMID: 6819525.6819525
110 Plotkin RP. Middle ear ventilation with the Castelli membrane tube. Laryngoscope 1981 Jul;91(7):1173–5. PMID: 7195446.7195446
111 Mandel EM, Casselbrant ML, Kurs-Lasky M. Acute otorrhea: bacteriology of a common complication of tympanostomy tubes. Ann Otol Rhinol Laryngol 1994 Sep;103(9):713–8. PMID: 8085732.8085732
112 Brown JA. Management of ventilation tubes: preventing premature extrusion. J S C Med Assoc 1993 Sep;89(9):427–30. PMID: 8231117.8231117
113 Debruyne F, Degroote M. One-year follow-up after tympanostomy tube insertion for recurrent acute otitis media. ORL J Otorhinolaryngol Relat Spec 1993 Jul–Aug;55(4):226–9. PMID: 8336923.8336923
114 Owen MJ, Norcross-Nechay K, Howie VM. Brainstem auditory evoked potentials in young children before and after tympanostomy tube placement. Int J Pediatr Otorhinolaryngol 1993 Jan;25(1–3):105–17. PMID: 8436453.8436453
115 Heaton JM, Mills RP. Otorrhoea via ventilation tubes in adults and children. Clin Otolaryngol Allied Sci 1993 Dec;18(6):496–9. PMID: 8877228.8877228
116 Siddiqui N, Toynton S, Mangat KS. Results of middle ear ventilation with ‘Mangat’ T-tubes. Int J Pediatr Otorhinolaryngol 1997 Jun 20;40(2–3):91–6. PMID: 9225174.9225174
117 Golz A, Netzer A, Joachims HZ, . Ventilation tubes and persisting tympanic membrane perforations. Otolaryngol Head Neck Surg 1999 Apr;120(4):524–7. PMID: 10187945.10187945
118 Valtonen H, Qvarnberg Y, Nuutinen J. Tympanostomy in young children with recurrent otitis media. A long-term follow-up study. J Laryngol Otol 1999 Mar;113(3):207–11. PMID: 10435125.10435125
119 Rosenfeld RM, Bhaya MH, Bower CM, . Impact of tympanostomy tubes on child quality of life. Arch Otolaryngol Head Neck Surg 2000 May;126(5):585–92. PMID: 10807325.10807325
120 Ah-Tye C, Paradise JL, Colborn DK. Otorrhea in young children after tympanostomy-tube placement for persistent middle-ear effusion: prevalence, incidence, and duration. Pediatrics 2001 Jun;107(6):1251–8. PMID: 11389239.11389239
121 Valtonen H, Dietz A, Qvarnberg Y. Long-term clinical, audiologic, and radiologic outcomes in palate cleft children treated with early tympanostomy for otitis media with effusion: a controlled prospective study. Laryngoscope 2005 Aug;115(8):1512–6. doi: 10.1097/01.mlg.0000172207.59888.a2. PMID: 16094135.16094135
122 Pereira MB, Pereira DR, Costa SS. Tympanostomy tube sequelae in children with otitis media with effusion: a three-year follow-up study. Braz J Otorhinolaryngol 2005 Jul–Aug;71(4):415–20. doi:10.1590/S0034-72992005000400003. PMID: 16446953.16446953
123 Spielmann PM, McKee H, Adamson RM, . Follow up after middle-ear ventilation tube insertion: what is needed and when? J Laryngol Otol. 2008 Jun;122(6):580–3. doi: 10.1017/s0022215107001168. PMID: 18047760.18047760
124 O’Reilly RC, He Z, Bloedon E, . The role of extraesophageal reflux in otitis media in infants and children. Laryngoscope 2008 Jul;118(7 Part 2 Suppl 116):1–9. doi: 10.1097/MLG.0b013e31817924a3. PMID: 18594333.18594333
125 Ida JB, Worley NK, Amedee RG. Gold laser adenoidectomy: long-term safety and efficacy results. Int J Pediatr Otorhinolaryngol 2009 Jun;73(6):829–31. doi: 10.1016/j.ijporl.2009.02.020. PMID: 19324425.19324425
126 Jung H, Lee SK, Cha SH, . Current bacteriology of chronic otitis media with effusion: high rate of nosocomial infection and decreased antibiotic sensitivity. J Infect 2009 Nov;59(5):308–16. doi: 10.1016/j.jinf.2009.08.013. PMID: 19715725.19715725
127 Kinnari TJ, Aarnisalo AA, Rihkanen H, . Can head position after anesthesia cause occlusion of the tympanostomy tube? J Otolaryngol Head Neck Surg. 2010 Feb;39(1):1–4. PMID: 20122337.20122337
128 Marzouk HA, Nathawad R, Hammerschlag MR, . Methicillin-resistant Staphylococcus aureus colonization in otitis-prone children. Arch Otolaryngol Head Neck Surg 2011 Dec;137(12):1217–22. doi: 10.1001/archoto.2011.192. PMID: 22183900.22183900
129 Tuli BS, Parmar TL, Singh B. Evaluation of tympanostomy tubes in middle ear affections. Indian J Otolaryngol Head Neck Surg 2001 Jul;53(3):217–20. doi: 10.1007/bf03028558. PMID: 23119801.23119801
130 Saki N, Nikakhlagh S, Salehe F, . Incidence of Complications Developed after the Insertion of Ventilation Tube in Children under 6 years old in 2008–2009. Iran J Otorhinolaryngol 2012 Winter;24(66):15–8. PMID: 24303379.24303379
131 Smillie I, Robertson S, Yule A, . Complications of ventilation tube insertion in children with and without cleft palate: a nested case-control comparison. JAMA Otolaryngol Head Neck Surg 2014 Oct;140(10):940–3. doi: 10.1001/jamaoto.2014.1657. PMID: 25171763.25171763
132 Luo HN, Ma SJ, Sheng Y, . Pepsin deteriorates prognosis of children with otitis media with effusion who undergo myringotomy or tympanostomy tube insertion. Int J Pediatr Otorhinolaryngol 2014 Dec;78(12):2250–4. doi: 10.1016/j.ijporl.2014.10.026. PMID: 25465449.25465449
133 Powell J, Powell S, Lennon M, . Paediatric ventilation tube insertion: our experience of seventy-five children in audiology-led follow-up. Clin Otolaryngol 2015 Aug;40(4):385–9. doi: 10.1111/coa.12380. PMID: 25598389.25598389
134 Birck HG, Mravec JJ. Myringostomy for middle ear effusions. Results of a two-year study. Ann Otol Rhinol Laryngol. 1976 Mar–Apr;85(2 Suppl 25 Pt 2):263–7. PMID: 1267356.1267356
135 Mackenzie IJ. Factors affecting the extrusion rates of ventilation tubes. J R Soc Med 1984 Sep;77(9):751–3. PMID: 6541254.6541254
136 Eliachar I, Joachims HZ, Goldsher M, . Assessment of long-term middle ear ventilation. Acta Otolaryngol 1983 Jul–Aug;96(1–2):105–12. PMID: 6613541.6613541
137 Jamal TS. Avoidance of postoperative blockage of ventilation tubes. Laryngoscope 1995 Aug;105(8 Pt 1):833–4. doi: 10.1288/00005537-199508000-00012. PMID: 7543180.7543180
138 Walker P. Ventilation tube duration versus site of placement. Aust N Z J Surg 1997 Aug;67(8):571–2. PMID: 9287928.9287928
139 Roland PS, Kreisler LS, Reese B, . Topical ciprofloxacin/dexamethasone otic suspension is superior to ofloxacin otic solution in the treatment of children with acute otitis media with otorrhea through tympanostomy tubes. Pediatrics 2004 Jan;113(1 Pt 1):e40–6. PMID: 14702493.14702493
140 Wallace HC, Newbegin CJ. Does ENT outpatient review at 1-week post ventilation tube insertion improve outcome at 1 month in paediatric patients? Clin Otolaryngol Allied Sci. 2004 Dec;29(6):595–7. doi: 10.1111/j.1365-2273.2004.00869.x. PMID: 15533143.15533143
141 Allen J, Morton RP, Ahmad Z. Early post–operative morbidity after tympanostomy tube insertion. J Laryngol Otol 2005 Sep;119(9):699–703. PMID: 16156910.16156910
142 Dohar J, Giles W, Roland P, . Topical ciprofloxacin/dexamethasone superior to oral amoxicillin/clavulanic acid in acute otitis media with otorrhea through tympanostomy tubes. Pediatrics 2006 Sep;118(3):e561–9. doi: 10.1542/peds.2005-2033. PMID: 16880248.16880248
143 Muenker G. Results after treatment of otitis media with effusion. Ann Otol Rhinol Laryngol Suppl. 1980 May–Jun;89(3 Pt 2):308–11. PMID: 6778334.6778334
144 van Baarle PW, Wentges RT. Extrusion of transtympanic ventilating tubes, relative to the site of insertion. ORL J Otorhinolaryngol Relat Spec 1975;37(1):35–40. PMID: 1169745.1169745
145 Kokko E, Palva T. Clinical results and complications of tympanostomy. Ann Otol Rhinol Laryngol 1976 Mar–Apr;85(2 Suppl 25 Pt 2):277–9. PMID: 1267359.1267359
146 Paradise JL, Bluestone CD, Rogers KD, . Efficacy of adenoidectomy for recurrent otitis media in children previously treated with tympanostomy-tube placement. Results of parallel randomized and nonrandomized trials. JAMA 1990 Apr 18;263(15):2066–73. PMID: 2181158.2181158
147 MacKinnon DM. The sequel to myringotomy for exudative otitis media. J Laryngol Otol 1971 Aug;85(8):773–94. PMID: 4105168.4105168
148 Daly KA, Hunter LL, Lindgren BR, . Chronic otitis media with effusion sequelae in children treated with tubes. Arch Otolaryngol Head Neck Surg 2003 May;129(5):517–22. doi: 10.1001/archotol.129.5.517. PMID: 12759263.12759263
149 Praveen CV, Terry RM. Does passive smoking affect the outcome of grommet insertion in children? J Laryngol Otol. 2005 Jun;119(6):448–54. doi: 10.1258/0022215054273197. PMID: 15992470.15992470
150 Khan F, Asif M, Farooqi GH, . Management outcome of secretory otitis media. J Ayub Med Coll Abbottabad 2006 Jan–Mar;18(1):55–8. PMID: 16773972.16773972
151 Hammaren-Malmi S, Saxen H, Tarkkanen J, . Passive smoking after tympanostomy and risk of recurrent acute otitis media. Int J Pediatr Otorhinolaryngol 2007 Aug;71(8):1305–10. doi: 10.1016/j.ijporl.2007.05.010. PMID: 17582514.17582514
152 Fiebach A, Matschke RG. [Duration and complications following grommet insertion in childhood]. HNO 1987 Feb;35(2):61–6. PMID: 3570884.3570884
153 Fior R, Veljak C. Late results and complications of tympanostomy tube insertion for prophylaxis of recurrent purulent otitis media in pediatric age. Int J Pediatr Otorhinolaryngol 1984 Dec;8(2):139–46. PMID: 6526581.6526581
154 Van Cauwenberge P, Cauwe F, Kluyskens P. The long-term results of the treatment with transtympanic ventilation tubes in children with chronic secretory otitis media. Int J Pediatr Otorhinolaryngol 1979 Sep;1(2):109–16. PMID: 576016.576016
155 Tos M, Poulsen G. Secretory otitis media. Late results of treatment with grommets. Arch Otolaryngol 1976 Nov;102(11):672–5. PMID: 985199.985199
156 Costa OA, Balieiro RO. Secretory otitis media in Brazilian children. Scand Audiol Suppl. 1986;26:93–4. PMID: 3472336.3472336
157 Barfoed C, Rosborg J. Secretory otitis media. Long-term observations after treatment with grommets. Arch Otolaryngol 1980 Sep;106(9):553–6. PMID: 7190819.7190819
158 Levine S, Daly K, Giebink GS. Tympanic membrane perforations and tympanostomy tubes. Ann Otol Rhinol Laryngol Suppl. 1994 May;163:27–30. PMID: 8179266.8179266
159 Hampton SM, Adams DA. Perforation rates after ventilation tube insertion: does the positioning of the tube matter? Clin Otolaryngol Allied Sci. 1996 Dec;21(6):548–9. PMID: 9118580.9118580
160 Postma DS, Poole MD, Wu SM, . The impact of day care on ventilation tube insertion. Int J Pediatr Otorhinolaryngol 1997 Sep 18;41(3):253–62. PMID: 9350484.9350484
161 Valtonen HJ, Qvarnberg YH, Nuutinen J. Otological and audiological outcomes five years after tympanostomy in early childhood. Laryngoscope 2002 Apr;112(4):669–75. doi: 10.1097/00005537-200204000-00014. PMID: 12150521.12150521
162 Valtonen H, Tuomilehto H, Qvarnberg Y, . A 14-year prospective follow-up study of children treated early in life with tympanostomy tubes: Part 1: Clinical outcomes. Arch Otolaryngol Head Neck Surg 2005 Apr;131(4):293–8. doi: 10.1001/archotol.131.4.293. PMID: 15837895.15837895
163 De Beer BA, Schilder AG, Zielhuis GA, . Natural course of tympanic membrane pathology related to otitis media and ventilation tubes between ages 8 and 18 years. Otol Neurotol 2005 Sep;26(5):1016–21. PMID: 16151352.16151352
164 Carignan M, Dorion D, Stephenson MF, . First myringotomy with insertion of a modified Goode T-Tube: changing the perforation paradigm. J Otolaryngol 2006 Oct;35(5):287–91. PMID: 17049144.17049144
165 Florentzson R, Finizia C. Transmyringeal ventilation tube treatment: a 10-year cohort study. Int J Pediatr Otorhinolaryngol 2012 Aug;76(8):1117–22. doi: 10.1016/j.ijporl.2012.04.013. PMID: 22648089.22648089
166 O’Niel MB, Cassidy LD, Link TR, . Tracking tympanostomy tube outcomes in pediatric patients with otitis media using an electronic database. Int J Pediatr Otorhinolaryngol 2015 Aug;79(8):1275–8. doi: 10.1016/j.ijporl.2015.05.029. PMID: 26115935.26115935
167 Gundersen T, Tonning FM. Ventilating tubes in the middle ear. Arch Otolaryngol 1976 Apr;102(4):198–9. PMID: 1267702.1267702
168 Tos M, Stangerup SE, Larsen P. Dynamics of eardrum changes following secretory otitis. A prospective study. Arch Otolaryngol Head Neck Surg 1987 Apr;113(4):380–5. PMID: 3814387.3814387
169 Slack RW, Maw AR, Capper JW, . Prospective study of tympanosclerosis developing after grommet insertion. J Laryngol Otol 1984 Aug;98(8):771–4. PMID: 6470572.6470572
170 Daly KA, Hunter LL, Levine SC, . Relationships between otitis media sequelae and age. Laryngoscope 1998 Sep;108(9):1306–10. PMID: 9738746.9738746
171 Koc A, Uneri C. Sex distribution in children with tympanosclerosis after insertion of a tympanostomy tube. Eur Arch Otorhinolaryngol 2001 Jan;258(1):16–9. PMID: 11271428.11271428
172 Friedman EM, Sprecher RC, Simon S, . Quantitation and prevalence of tympanosclerosis in a pediatric otolaryngology clinic. Int J Pediatr Otorhinolaryngol 2001 Sep 28;60(3):205–11. PMID: 11551611.11551611
173 Bonding P, Lorenzen E. Chronic secretory otitis media--long-term results after treatment with grommets. ORL J Otorhinolaryngol Relat Spec 1974;36(4):227–35. PMID: 4215997.4215997
174 Bonding P, Lorenzen E. Cicatricial changes of the eardrum after treatment with grommets. Acta Otolaryngol 1973 Apr;75(4):275–6. PMID: 4702615.4702615
175 Li Y, Hunter LL, Margolis RH, . Prospective study of tympanic membrane retraction, hearing loss, and multifrequency tympanometry. Otolaryngol Head Neck Surg 1999 Nov;121(5):514–22. PMID: 10547462.10547462
176 Tos M, Poulsen G. Attic retractions following secretory otitis. Acta Otolaryngol 1980 May–Jun;89(5–6):479–86. PMID: 7192477.7192477
177 Golz A, Goldenberg D, Netzer A, . Cholesteatomas associated with ventilation tube insertion. Arch Otolaryngol Head Neck Surg 1999 Jul;125(7):754–7. PMID: 10406312.10406312
178 Spilsbury K, Ha JF, Semmens JB, . Cholesteatoma in cleft lip and palate: a population-based follow-up study of children after ventilation tubes. Laryngoscope 2013 Aug;123(8):2024–9. doi: 10.1002/lary.23753. PMID: 23737350.23737350
179 Djurhuus BD, Christensen K, Skytthe A, . The impact of ventilation tubes in otitis media on the risk of cholesteatoma on a national level. Int J Pediatr Otorhinolaryngol 2015 Apr;79(4):605–9. doi: 10.1016/j.ijporl.2015.02.005. PMID: 25724629.25724629
180 Goldstein NA, Mandel EM, Kurs-Lasky M, . Water precautions and tympanostomy tubes: a randomized, controlled trial. Laryngoscope 2005 Feb;115(2):324–30. doi: 10.1097/01.mlg.0000154742.33067.fb. PMID: 15689760.15689760
181 Parker GS, Tami TA, Maddox MR, . The effect of water exposure after tympanostomy tube insertion. Am J Otolaryngol 1994 May–Jun;15(3):193–6. PMID: 8024107.8024107
182 Becker GD, Eckberg TJ, Goldware RR. Swimming and tympanostomy tubes: a prospective study. Laryngoscope 1987 Jun;97(6):740–1. PMID: 3586818.3586818
183 Cohen HA, Kauschansky A, Ashkenasi A, . Swimming and grommets. J Fam Pract 1994 Jan;38(1):30–2. PMID: 8289048.8289048
184 el Silimy O, Bradley PJ. Bacteriological aspects of swimming with grommets. Clin Otolaryngol Allied Sci 1986 Oct;11(5):323–7. PMID: 3780019.3780019
185 Francois M, Jaquemin P, Margo JN, . [Swimming and ventilating tubes. Results of a multicenter study]. Ann Pediatr (Paris) 1992 Dec;39(10):627–9. PMID: 1485779.1485779
186 Kaufmann TU, Veraguth D, Linder TE. [Water precautions after insertion of a tympanostomy tube: necessary or obsolete?]. Schweiz Med Wochenschr 1999 Oct 9;129(40):1450–5. PMID: 10546304.10546304
187 Salata JA, Derkay CS. Water precautions in children with tympanostomy tubes. Arch Otolaryngol Head Neck Surg 1996 Mar;122(3):276–80. PMID: 8607955.8607955
188 Sharma PD. Swimming with grommets. Scand Audiol Suppl. 1986;26:89–91. PMID: 3472335.3472335
189 Smelt GJ, Yeoh LH. Swimming and grommets. J Laryngol Otol 1984 Mar;98(3):243–5. PMID: 6538215.6538215
190 Konradsson K, Ortegren U. [Transmyringeal ventilation tubes: postoperative restrictions and early complications]. Lakartidningen 1986 Oct 15;83(42):3514–7. PMID: 3784716.3784716
191 Waycaster C, Cockrum P, Reese B, . Treatment of Acute Otitis Media in Children with Tympanostomy Tubes: A Caregiver’s Perspective. Pharmacy and Therapeutics 2004;29(11):721–30.
192 Goldblatt EL, Dohar J, Nozza RJ, . Topical ofloxacin versus systemic amoxicillin/clavulanate in purulent otorrhea in children with tympanostomy tubes. Int J Pediatr Otorhinolaryngol 1998 Nov 15;46(1–2):91–101. PMID: 10190709.10190709
193 Ruohola A, Heikkinen T, Jero J, . Oral prednisolone is an effective adjuvant therapy for acute otitis media with discharge through tympanostomy tubes. J Pediatr 1999 Apr;134(4):459–63. PMID: 10190921.10190921
194 Dohar JE, Garner ET, Nielsen RW, . Topical ofloxacin treatment of otorrhea in children with tympanostomy tubes. Arch Otolaryngol Head Neck Surg 1999 May;125(5):537–45. PMID: 10326811.10326811
195 Ruohola A, Heikkinen T, Meurman O, . Antibiotic treatment of acute otorrhea through tympanostomy tube: randomized double-blind placebo-controlled study with daily follow-up. Pediatrics 2003 May;111(5 Pt 1):1061–7. PMID: 12728089.12728089
196 Roland PS, Anon JB, Moe RD, . Topical ciprofloxacin/dexamethasone is superior to ciprofloxacin alone in pediatric patients with acute otitis media and otorrhea through tympanostomy tubes. Laryngoscope 2003 Dec;113(12):2116–22. doi: 10.1097/00005537-200312000-00011. PMID: 14660913.14660913
197 Granath A, Rynnel-Dagoo B, Backheden M, . Tube associated otorrhea in children with recurrent acute otitis media; results of a prospective randomized study on bacteriology and topical treatment with or without systemic antibiotics. Int J Pediatr Otorhinolaryngol 2008 Aug;72(8):1225–33. doi: 10.1016/j.ijporl.2008.04.015. PMID: 18565598.18565598
198 Heslop A, Lildholdt T, Gammelgaard N, . Topical ciprofloxacin is superior to topical saline and systemic antibiotics in the treatment of tympanostomy tube otorrhea in children: the results of a randomized clinical trial. Laryngoscope 2010 Dec;120(12):2516–20. doi: 10.1002/lary.21015. PMID: 20979100.20979100
199 van Dongen TM, van der Heijden GJ, Venekamp RP, . A trial of treatment for acute otorrhea in children with tympanostomy tubes. N Engl J Med 2014 Feb 20;370(8):723–33. doi: 10.1056/NEJMoa1301630. PMID: 24552319.24552319
200 van Dongen TM, Venekamp RP, Wensing AM, . Acute otorrhea in children with tympanostomy tubes: prevalence of bacteria and viruses in the post-pneumococcal conjugate vaccine era. Pediatr Infect Dis J 2015 Apr;34(4):355–60. doi: 10.1097/inf.0000000000000595. PMID: 25764097.25764097
201 Roland PS, Dohar JE, Lanier BJ, . Topical ciprofloxacin/dexamethasone otic suspension is superior to ofloxacin otic solution in the treatment of granulation tissue in children with acute otitis media with otorrhea through tympanostomy tubes. Otolaryngol Head Neck Surg 2004 Jun;130(6):736–41. doi: 10.1016/j.otohns.2004.02.037. PMID: 15195060.15195060
202 Strachan D, Clarke SE, England RJ. The effectiveness of topical treatment in discharging ears with in-dwelling ventilation tubes. Rev Laryngol Otol Rhinol (Bord) 2000;121(1):27–9. PMID: 10865480.10865480
203 Rovers MM, Black N, Browning GG, . Grommets in otitis media with effusion: an individual patient data meta-analysis. Arch Dis Child 2005 May;90(5):480–5. doi: 10.1136/adc.2004.059444. PMID: 15851429.15851429
204 Kay DJ, Nelson M, Rosenfeld RM. Meta-analysis of tympanostomy tube sequelae. Otolaryngol Head Neck Surg 2001 Apr;124(4):374–80. PMID: 11283489.11283489
205 Idicula WK, Jurcisek JA, Cass ND, . Identification of biofilms in post-tympanostomy tube otorrhea. Laryngoscope 2016 Aug;126(8):1946–51. doi: 10.1002/lary.25826. PMID: 27426942.27426942