# Methods

The Brown Evidence-based Practice Center (EPC) conducted this review based on a systematic review of the published scientific literature using established methodologies as outlined in the Agency for Healthcare Research and Quality’s (AHRQ) Methods Guide for Effectiveness and Comparative Effectiveness Reviews.^21^ The PROSPERO protocol registration number is CRD42015029623.

## Eligibility Criteria

We use the Population, Intervention, Comparator, Outcomes, and Designs (PICOD) formalism to define the characteristics of the eligible studies for this review.

### Populations

For all KQs, studies of children and adolescents from 1 month to 18 years old were eligible. We defined five age groups, namely infants (28 days to 12 months), toddlers (13 months to 2 years), early childhood (2 to 5 years), middle childhood (6 to 11 years), and early adolescence (12 to 18 years).^22^ Subpopulations of interest included children at high risk of recurrent AOM or OME, such as children with Down syndrome, cleft palate, other craniofacial anomalies, or primary ciliary dyskinesia; and children at high risk of adverse clinical or developmental outcomes, such as those with preexisting hearing loss, speech and language problems, or various developmental disorders. We were also interested in the population of children who have sociodemographic risk factors (e.g. day care exposure or low socioeconomic status).

For Key Question (KQ) 1, we included studies of children with chronic OME. We preferred the standard definition of effusion that persists for at least 3 months,^1^ but also included results based on studies’ alternative definitions, if our preferred one was not reported. We excluded studies of children with chronic suppurative otitis media since it is associated with a persistently perforated tympanic membrane.

For KQ 2, we included children with recurrent AOM with or without middle ear effusion, defined as three or more well-documented and separate AOM episodes in the past 6 months or at least four well-documented and separate AOM episodes in the past 12 months with at least one in the past 6 months.^23^ For studies that did not report the preferred definition we recorded the study specific definition.

For KQ 3 and 4, we included studies in children with TT placed for OME or AOM. For KQ 5, we included studies of symptomatic or asymptomatic children with acute TT otorrhea beyond the immediate postoperative period. We defined the immediate postoperative period as 30 days after surgery, but included studies reporting results near that period (e.g., 28 days, 4 weeks).

### Interventions/Exposures

For KQs 1, 2, and 3 we considered all studies that included myringtomy with TT placement, with or without adenoidectomy. Tubes were classified as short-term tubes (generally in place for 10–18 months) and long-term tubes (e.g. T-tubes, which typically remain in place for several years).

In KQ 4, we distinguished three categories of interventions; avoidance (e.g. of swimming or head immersion while bathing), canal occlusion methods (e.g. earplugs or headbands), and postexposure prophylaxis using ototopical antibiotics.

In KQ 5 we compared ototopical preparations, including FDA approved products (i.e. ofloxacin otic 0.3%, ciprofloxacin 0.3% & dexamethasone 0.1%), and other non FDA-approved agents (e.g. hydrocortisone & bacitracin & colistin).

### Comparators

For KQ 1, comparisons of primary interest were watchful waiting or adenoidectomy. Comparators for KQ2 included watchful waiting, with systemic or topical antibiotic therapy for recurrent episodes of AOM, prophylactic antibiotics and adenoidectomy. KQ 3 did not address comparative harms. In KQ 4, comparators included no water precautions with or without avoidance of higher risk activities (e.g. diving or underwater swimming and ear plugs or swimming caps). The primary comparators for KQ5 were watchful waiting and oral antibiotic therapy.

### Outcomes

For KQs 1 and 2, which address the effectiveness of TT, we considered intermediate outcomes, including prevalence of middle ear effusion, measures of hearing and vestibular function, such as improved hearing thresholds (audibility), tests of auditory perception and discrimination (clarity), and balance and coordination (vestibular function). For KQ 2, measures of recurrent AOM, including otorrhea were also extracted.

Quality of life and patient-centered outcomes included global and otitis-specific child and parental quality of life, speech and language outcomes, educational achievement, and behavioral outcomes, such as disobedience, enuresis, or tantrums.

The following adverse event outcomes were extracted for KQ 3: Intraoperative and immediate postoperative anesthetic and surgical adverse events, otorrhea, blockage of the tube lumen, granulation tissue, premature extrusion, TT displacement into the middle ear, persistent perforation of the tympanic membrane, myringosclerosis, tympanic membrane atrophy, atelectasis and retraction pockets, worsened hearing thresholds, and other reported adverse events (plausibly related to TT). Studies reporting only postoperative otorrhea (during the 30 days after surgery )was excluded, as this outcome is likely confounded by the preoperative state of the middle ear.

Outcomes for KQ 4 (water precautions) included final health and patient-centered outcomes related to child and parental quality of life and intermediate outcomes related to the incidence and duration of otorrhea.

Outcomes evaluated relating to KQ 5 (treatment of otorrhea) included global and otitis-specific child and parental quality of life, duration of otorrhea, and need for removal of TT. Postoperative otorrhea was not an outcome of interest.

### Timing

We included studies with any duration of followup.

### Setting

Studies performed in both primary and specialty care settings were included.

### Study Design

We evaluated published, peer-reviewed studies only. Conference abstracts were excluded. For KQs 1 and 2, we included randomized comparative trials and nonrandomized comparative studies, prospective and retrospective, where treatment was assigned on a per patient basis. Studies with per ear assignment were excluded (e.g. TT placed by design in one ear only).

For KQ 3, we included prospective surgical studies enrolling at least 50 subjects (including arms of RCTs or NRCSs with 50 or more patients) and population based retrospective single-group studies (registry studies) with ≥1000 subjects.

## Evidence Identification

We conducted literature searches of all studies in MEDLINE®, both the Cochrane Central Trials Registry and Cochrane Database of Systematic Reviews, EMBASE®, and CINAHL® (from inception) to identify primary research studies meeting our criteria. We used the search strategies in Appendix A. The last search was run on May 19, 2016. The TEP was asked to provide citations of potentially relevant articles. Additionally, we perused the reference lists of published clinical practice guidelines, relevant narrative and systematic reviews, and examined Scientific Information Packages from manufacturers. Existing systematic reviews were used primarily as sources of studies; we extracted and incorporated all studies de novo, and did not summarize or incorporate existing systematic reviews, per se.

We searched Devices@FDA.gov at www.accessdata.fda.gov/scripts/cdrh/devicesatfda/ for the classification product code “ETD” (TT). This returned 109 records, all of which are deemed to be substantially equivalent to previous devices (indicating there are no new data that the FDA considered) or have original approvals that predate the electronic records and require either contacting the manufacturer for information or requesting it from the FDA. We also searched the Clinicaltrials.gov Web site and the WHO International Clinical Trials Registry Platform for relevant study records. All records identified were screened for eligibility using the same criteria as was used for articles identified through literature searches.

At the start of citation screening, we implemented a training session, in which all researchers screened the same articles and conflicts were discussed. We iteratively continued training until agreement was reached regarding the nuances of the eligibility criteria for screening. All citations found by literature searches, including from sources other than electronic databases (e.g., TEP, existing systematic reviews) were independently screened by two researchers. Conflicts were resolved by discussion until a group consensus was reached. All screening was done in the open-source, online software Abstrackr (http://abstrackr.cebm.brown.edu/).

## Data Extraction and Data Management

Each study was extracted by one methodologist. The extractions were reviewed and confirmed by at least one other methodologist. Any disagreements were resolved by discussion among the team members. Data was extracted into customized forms in the Systematic Review Data Repository (SRDR) online system (http://srdr.ahrq.gov). Upon completion of the review, the SRDR database will be made accessible to the general public with capacity to read, download, and comment on data. The basic elements and design of these forms is similar to those we have used for other comparative effectiveness reviews and includes elements that address population characteristics; descriptions of the interventions, exposures, and comparators analyzed; outcome definitions; effect modifiers; enrolled and analyzed sample sizes; study design features; funding source; results; and risk of bias questions.

## Assessment of Methodological Risk of Bias of Individual Studies

We assessed the methodological quality of each study based on predefined criteria. For RCTs, we used the Cochrane risk of bias tool,^24^ which asks about risk of selection bias, performance bias, detection bias, attrition bias, reporting bias, and other potential biases. For observational studies, we used relevant questions from the Newcastle Ottawa Scale.^25^ The methodological attributes of studies and comments on study execution and outcome measurement that pertain to specific outcomes within a study were considered when determining the overall strength of evidence for conclusions related to those outcomes, as is standard practice.

## Data Synthesis

All included studies were summarized in narrative form and in summary tables that tabulate the important features of the study populations, design, intervention, outcomes, and results.

We analyzed different study designs separately. We compared and contrasted populations, exposures, and results across study designs. We examined any differences in findings between observational and intervention studies. We evaluated the risk of bias factors as possible explanations for any heterogeneity.

Specific methods and metrics (summary measures) meta-analyzed were chosen based on available outcomes. We conducted quantitative analysis for outcomes that have at least five studies reporting results that could be combined in a meta-analysis. When available, these were summarized as odds ratios of categorical outcomes and net change of continuous outcomes (e.g., mean hearing threshold).

For KQ 4, we conducted direct pairwise random effects meta-analyses of nonrandomized comparative studies that were sufficiently similar in population, interventions (water restriction vs. ear protection), and outcomes. The two randomized comparative trials were not combined in a meta-analysis on the basis of clinical heterogeneity (suggestion of higher baseline risk), as well as methodological heterogeneity. Rather, each was individually reported. We used typical models that assume that study-specific latent treatment effects are normally distributed across studies,^26^ and estimated them by maximizing the restricted likelihood in a generalized linear mixed model, using the R^27^ package metafor.^28^

For KQs 1 and 5, we performed network meta-analysis of clinical outcomes to compare treatment alternatives. We conducted network meta-analyses in the Bayesian framework, using the R gemtc package.^29, 30^ A network meta-analysis is an extension of pairwise meta-analyses that simultaneously combines direct (when interventions are compared head-to-head) and indirect (when interventions are compared through other reference interventions) evidence. Combining the direct and indirect evidence not only improves precision of estimates, but also provides estimates for all pairwise comparisons, including those missing from the direct evidence. The key assumption of the network meta-analysis is that of consistency of direct and indirect effects. Consistency is likely to hold when the distribution of effect modifiers is (equivalently, patient characteristics are) similar across trials. If this assumption is violated, there may be inconsistency between the direct evidence and indirect evidence of treatment comparisons.

For network meta-analyses, we used a hierarchical model with a within-study level and a between-studies level that models responses at the arm level and nests arms within studies. We ran two sets of analyses, one assuming consistency of treatment effects and one examining this assumption. The models are shown in Appendix I. Briefly, the analysis assuming consistency parameterizes treatment effects as linear combinations of T-1 parameters, where T is the number of treatments in the network. Treatment effects are assumed to be normally distributed across studies with a common variance, i.e., are homoscedastic random effects. We used weakly informative default priors on study-level mean treatment effects and on between-study means and variances. Priors on the means were uniform distributions, with standard errors 15 times larger than the observed scatter of study effect estimates. We put uniform priors on the standard deviation of between-studies treatment effects, with support determined from the observed scatter of treatment effects.

Estimation was done with MCMC via the JAGS sampler,^31^ using initial values drawn randomly from the marginal distributions of the priors of respective parameters. We fit four MCMC chains. After a burn in of 5000 iterations, we monitored convergence of random effects means and variances automatically, by checking every 10000 iterations whether the Gelman Rubin diagnostic was less than 1.05 with 95% probability for all monitored parameters. After convergence was reached, an extra 10000 iterations were run. All models converged quickly, within 10000 iterations. Model fit was assessed by comparing the posterior mean of the residual deviance to the number of data points.^32^ The ratio of residual deviance to number of data points ranged from 0.97 to 1.06, suggesting adequate model fit.

For each analysis, we empirically assessed if the network meta-analysis consistency assumption was violated by comparing the direct and indirect evidence using a node-splitting approach. We separately parameterized the direct and indirect effects, and compared the estimates of the two.^33, 34^ These analyses were not suggestive of inconsistency, but in small networks, like the ones in this report, they can be underpowered. The split-node analysis is the statistically preferred version of naive analyses that compare direct and indirect estimates in a network. Formal model description, details of inconsistency analysis and illustrative trace and density plots are shown in Appendix I.

Results are presented in terms of means and corresponding 95% credible intervals (CrI). We also estimated the probability that a treatment is the most effective, second most effective, and so on, based on the results of the network meta-analyses.

Statistical heterogeneity was explored qualitatively. Because of the relatively small number of studies, and the little variability in characteristics, meta-regression analyses were not performed. Instead, we did subgroup analyses for the study characteristics of interest described in the corresponding KQ. Because these subgroup analyses did not change conclusions, they are not reported in detail.

## Grading the Strength of Evidence

We graded the strength of evidence (SOE) as per the AHRQ methods guide on assessing the strength of evidence.^35^ We assessed the strength of evidence for each outcome. Following the standard AHRQ approach, for each intervention and comparison of intervention and for each outcome, we assessed the number of studies, their study designs, the study limitations (i.e., risk of bias and overall methodological quality), the directness of the evidence to the KQs, the consistency of study results, the precision of any estimates of effect, the likelihood of reporting bias, and the overall findings across studies. Based on these assessments, we assigned a strength of evidence rating as being either high, moderate, or low, or there being insufficient evidence to estimate an effect.

## Assessing Applicability

We assessed the direct applicability within and across studies with reference to children with specific comorbidities (Down syndrome, cleft palate, etc.), and whether interventions and comparators are used in current practice.