# Technical Expert Panel

In designing the study questions and methodology at the outset of this report, the EPC consulted several technical and content experts. Broad expertise and perspectives were sought. Divergent and conflicting opinions are common and perceived as healthy scientific discourse that results in a thoughtful, relevant systematic review. Therefore, in the end, study questions, design, methodologic approaches, and/or conclusions do not necessarily represent the views of individual technical and content experts.

Technical Experts must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential conflicts of interest identified.

The list of Technical Experts who provided input to this report follows:

- Alison Grimes, Au.D.^*^
  Audiology Department
  UCLA Medical Center
  Los Angeles, CA
- David Hoelting, M.D.
  Pender Medical Clinic
  Pender Community Hospital
  Pender, NE
- Howard J. Hoffman, B.S., M.A.^*^
  Epidemiology and Statistics Program
  Division of Scientific Programs
  National Institute on Deafness and Other Communication Disorders
  National Institutes of Health
  U.S. Department of Health and Human Services
  Bethesda, MD
- Richard Rosenfeld, M.D., M.P.H., FAAP^*^
  Department of Otolaryngology
  SUNY Downstate Medical Center
  Brooklyn, NY
- Lorry Rubin, MD^*^
  Hofstra North Shore-LIJ School of Medicine
  Hempstead, NY
- David E. Tunkel, M.D.^*^
  Director of Pediatric Otolaryngology
  Johns Hopkins University School of Medicine
  Baltimore, MD
- Roderick Venekamp, M.D., M.Sc., Ph.D.^*^
  University Medical Center Utrecht
  Julius Center for Health Sciences and Primary Care & Department of Otorhinolaryngology
  The Netherlands

* Provided input on draft report.