# Key Informants

In designing the study questions, the EPC consulted several Key Informants who represent the end-users of research. The EPC sought the Key Informant input on the priority areas for research and synthesis. Key Informants are not involved in the analysis of the evidence or the writing of the report. Therefore, in the end, study questions, design, methodological approaches, and/or conclusions do not necessarily represent the views of individual Key Informants.

Key Informants must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their role as end-users, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any conflicts of interest.

The list of Key Informants who provided input to this report follows:

- Margaretha Casselbrandt, M.D., Ph.D.^*^
  Department of Pediatric Otolaryngology
  Children’s Hospital of Pittsburgh
  Pittsburgh, PA
- Alison Grimes, Au.D.^*^
  Audiology Department
  UCLA Medical Center
  Los Angeles, CA
- David Hoelting, M.D.
  Pender Medical Clinic
  Pender Community Hospital
  Pender, NE
- Alison Kelly, B.S.N., R.N., C.P.E.N.
  Hasbro Children’s Hospital
  Providence, RI
- Josiah Morse, M.P.H.
  Washington State Health Technology Assessment Program
  Olympia, WA
- Richard Rosenfeld, M.D., M.P.H., FAAP^*^
  Department of Otolaryngology
  SUNY Downstate Medical Center
  Brooklyn, NY
- David E. Tunkel, M.D.^*^
  Director of Pediatric Otolaryngology
  Johns Hopkins University School of Medicine
  Baltimore, MD

* Provided input on draft report.