# Discussion

## Overall Summary and Strength of Evidence

Our systematic review of 172 publications focused on five Key Questions (KQ), which evaluate the evidence for the effectiveness of tympanostomy tubes (TT) in children with chronic middle ear effusion and recurrent acute otitis media, the adverse events (harms) associated with this procedure, the need for water precautions in children with TT, and the treatment of TT otorrhea.

### Key Question 1

In children with chronic otitis media with effusion, 32 publications reported results of 22 RCTs. Hearing thresholds were obtained in 16 RCTs, and in 10 trials they were reported by arm at various time points.

TT placement (compared to watchful waiting) resulted in improved average hearing thresholds 1 to 3 months after surgery. During this period, when the majority of tubes are functioning, mean hearing thresholds decreased by an average of 9.1 dB (95% CrI −14 to −3.4). A similar improvement was seen for children treated with TT and adenoidectomy (10 dB [95% CrI −19 to −1.9]) improvement. No significant change in hearing thresholds was noted after treatment with myringotomy alone or with oral antibiotic prophylaxis.

By 1 to 2 years, when most tubes have extruded, hearing thresholds are no longer different, likely reflecting the favorable natural history of spontaneous resolution of middle ear effusion in most children. There was a trend suggesting improved thresholds in children undergoing adenoidectomy, but credible intervals are wide and include the null effect.

The IPD by Boonacker et. al., which relied on a post hoc composite outcome, concluded that adenoidectomy is most beneficial in children four years or older with persistent otitis media with effusion. In this group at 12 months, 51% of those who had adenoidectomy failed, whereas 70% of those who did not have adenoidectomy failed (Risk Difference 19%: 95% Cl 12% – 26%; NNT = 6). No significant benefit of adenoidectomy was found in children less than 4 years old.^2^

Data were very sparse with respect to which factors might predict those children more likely to benefit from TT. The individual patient data meta-analysis (IPD) reported by Rovers et. al. focused on interactions between treatment and baseline characteristics. They found significant interactions between daycare attendance in children 3 years or younger, and in children over 4 years of age with a hearing level of 25 dB or greater in both ears, and concluded that TT might be used in young children attending day-care; or in older children with a hearing level of 25 dB or baseline hearing level persisting for at least 12 weeks. They noted that average hearing level at baseline did not obviously modify the effect estimate.^203^

Quality of life and other patient-centered outcomes (cognitive, language, and behavioral) were reported in eight studies (five RCTs, three NRCSs, and one that combined both designs) in 12 papers. These studies reported on 119 quality of life and patient-centered outcomes in 1665 children over multiple time points and interventions. These studies reported only 14 outcomes with significant results. In general, the results were not significant and varied in magnitude and direction, even across subscales of the same test.

Overall, the evidence suggests that TT placement results in improved average hearing thresholds during early followup of 1 to 3 months after surgery. However, these improvements are not sustained at 1 to 2 years. There is limited evidence regarding quality of life outcomes, but neither of the two studies that evaluated parental stress and health related quality of life found significant improvements in surgically treated children. Evidence for improved cognitive, language, or behavioral outcomes after TT compared to watchful waiting is similarly lacking.

### Key Question 2

In children with recurrent acute otitis media, seven publications reported results of six RCTs. We were unable to provide pooled results due to the small number of studies, multiple interventions, and heterogeneity in reported outcomes. The limited available evidence suggests that TT placement decreases the number of further episodes and the overall number of episodes of recurrent AOM.

Although Kujala 2012 found that insertion of TT, without or without adenoidectomy, significantly reduced the risk of recurrent AOM, a subsequent publication of quality of life outcomes from this trial found no differences in overall ear-related quality of life between surgically treated groups and no-surgery groups, nor did they find any differences in the subscales of caregiver concern, emotional distress, physical suffering, activity limitations, hearing loss, or speech impairment.^96^

Very little evidence from RCTs is available to evaluate factors that identify children most likely to benefit from TT placement. A post hoc subgroup (n=22) comparison in one study concluded that patients with middle ear effusion at the time of surgical evaluation had improved outcomes.^90^ The other two studies specifically excluded patients with middle ear effusion.^91, 95^

Three RCTs consistently found no difference in recurrent episodes of AOM when comparing TT versus TT and adenoidectomy. However, the Boonaker 2014 IPD meta-analysis concluded that children less than 2 years old years with recurrent AOM had a greater chance of clinical improvement. In this younger group at 12 months, 16% of those who had adenoidectomy failed, whereas 27% of those who did not have adenoidectomy failed [RD 12%, 95% Cl: 6% to 18%; NNT = 9].^2^

### Key Question 3

In general, study specific definitions of adverse events were incompletely reported or highly variable between studies. Not all cohorts followed all patients until extrusion of the tube, nor was followup complete in all studies. Several adverse event categories have very wide interquartile ranges (e.g. otorrhea, premature extrusion, and myringosclerosis). This is likely because of highly variable definitions. For example, in some studies, counts of patients with at least one episode of otorrhea were included, while other studies included only patients with purulent ear discharge. Otorrhea is particularly complex to characterize, as it may with respect to frequency, duration, volume, character, and associated symptoms. Other adverse events, such as hearing loss and cholesteatoma, are likely confounded by the severity of preexisting and ongoing middle ear disease.

### Key Question 4

We identified nine studies, two RCTs and seven NRCSs that evaluate physical ear protection (e.g. ear plugs) or water restriction (e.g. no swimming or head immersion while bathing) in children after TT placement. A single RCT reported a slightly lower adjusted rate of otorrhea in children assigned to wear ear plugs. The unadjusted odds ratio of having one or more episodes of otorrhea was not significantly different (OR 0.68, 95% CI 0.37 to 1.25). A second RCT, with high risk of bias, found a nonsignificant difference in the odds ratio in nonswimmers versus swimmers (OR 0.71, 95% CI 0.29 to 1.76). Separate meta-analysis of NRCSs with evaluated ear protection and nonswimming tend to favor no precautions and swimming, but their confidence intervals do not exclude a null effect. In addition, the included NRCSs have high risk of confounding and other biases.

### Key Question 5

Seven studies were included in a network meta-analysis of the comparative effectiveness of various treatments for TT otorrhea. The common outcome evaluated was clinical cure, defined as absence of otorrhea after completion of treatment.

The odds of clinical cure were 12-fold (95% CrI: 1.9 – 82) higher [NNT 2.2 (assuming a baseline rate 0.45)]^a^ for antibiotic-glucocorticoid drops, compared to watchful waiting/placebo. Similarly, the odds of clinical cure were 7.3-fold (95% CrI: 1.2 – 51) higher [NNT 2.5 (assuming a baseline rate of 0.45)]^b^ for topical antibiotic drops (compared to watchful waiting/placebo).

Compared to oral antibiotics, treatment with topical-glucocorticoid drops demonstrated higher effectiveness, odds ratio 5.3 (95% CrI: 1.2 to 27) [NNT 3.2 (assuming a baseline rate 0.56)].^c^ The odds ratio for topical antibiotic drops was 3.3 (95% CrI: 0.74 – 16)[NNT 5 (assuming a baseline rate of 0.69)]^d^, although the credible interval includes 1.

An overall summary of main conclusions with an assessment of the strength of evidence is summarized in Table 18.

Table 18 Strength of evidence assessment

Key Question or Population | Outcome | Comparison | Risk of Bias for the evidence-base | Consistency | Precision | Directness | Overall Rating | Key Findings and Comments
Key Question 1
Effectiveness of TT in children with chronic MEE | Improvement (decrease) in mean hearing level 1–3 months | TT vs. Watchful waiting | Moderate to high | Consistent | Somewhat imprecise | Mix of direct and indirect from network MA | Moderate | 6 RCT Effective: − 9.1 dB (CrI: −14.5, −3.2)
Effectiveness of TT in children with chronic MEE | Improvement (decrease) in mean hearing level 1–3 months
Effectiveness of TT in children with chronic MEE | Improvement (decrease) in mean hearing level 1–3 months | TT & Adenoidectomy vs. Watchful waiting | Moderate to high | Consistent | Somewhat imprecise | Mix of direct and indirect from network MA | Moderate | 6 RCT Effective: −10.3 dB (CrI: −18.6, −1.6)
Effectiveness of TT in children with chronic MEE
Effectiveness of TT in children with chronic MEE | Improvement (decrease) in mean hearing level (12–24 months) | TT vs. Watchful waiting | Moderate to high | Consistent | Mostly precise | Mix of direct and indirect from network MA | Moderate | 5 RCT Not effective: 0.03 dB (CrI: −3.9, 3.3)
Effectiveness of TT in children with chronic MEE | Improvement (decrease) in mean hearing level (12–24 months)
Effectiveness of TT in children with chronic MEE | Improvement (decrease) in mean hearing level (12–24 months) | TT & Adenoidectomy vs. Watchful waiting | Moderate to high | Consistent | Imprecise | Mix of direct and indirect from network MA | Insufficient | 5 RCT Possibly effective: −3.8 dB (CrI: −8.5, 0.62
Effectiveness of TT in children with chronic MEE
Effectiveness of TT in children with chronic MEE | Decrease in mean duration of time with middle ear effusion | TT vs. Watchful waiting | Moderate to high | Consistent | Imprecise | Mix of direct and indirect from network MA | Insufficient | 6 RCT Possibly effective: −17 weeks (CrI: −40.0, 4.9)
Effectiveness of TT in children with chronic MEE
Effectiveness of TT in children with chronic MEE | | TT & Adenoidectomy vs. Watchful waiting | Moderate to high | Consistent | Imprecise | Mix of direct and indirect from network MA | Insufficient | 6 RCT Possibly effective: −23 weeks (CrI: −56.0, 9.9)
Effectiveness of TT in children with chronic MEE
Effectiveness of TT in children with chronic MEE | Quality of life and patient –centered outcomes | TT vs Watchful waiting | Low to moderate | Consistent | Imprecise | Direct | Low | 5 RCTs, 3 NRCSs Not effective Multiple outcomes No quantitative synthesis done
Effectiveness of TT in children with chronic MEE
Effectiveness of TT in children with chronic MEE | Hearing test as a modifier of effectiveness | | Moderate to high | Unknown | Imprecise | Direct | Insufficient | No quantitative synthesis done
Effectiveness of TT in children with chronic MEE
Effectiveness of TT in children with chronic MEE | Other patient factors which modify effectiveness of TT | | Moderate to high | Unknown | Imprecise | Direct | Insufficient | No quantitative synthesis Sparse reporting of potential predictors
Separately for populations at high risk (e.g. cleft palate, Down syndrome) | various | | High | Inconsistent | Imprecise | Direct | Insufficient | No RCTs 6 NRCSs
Key Question 2
Tympanostomy tubes in children with recurrent AOM | | TT vs. Watchful waiting | High | Consistent | Imprecise | Direct | Low | 6 RCTs (1049 patients) No quantitative synthesis Magnitude of clinically important effects unclear
| | TT vs. TT & Adenoidectomy | Moderate to high | Consistent | Imprecise | Direct | Low | 3 RCTs No quantitative synthesis
| Quality of Life | TT vs. Watchful waiting | Moderate | NA | Imprecise | Direct | Low | 1 RCT
| Factors which identify children most likely to benefit | TT vs. Watchful waiting | High | Unknown | Imprecise | Indirect | Insufficient
Key Question 4
Ear plugs or water restrictions in children with TT | Average rate of otorrhea | Ear plugs vs. no precautions | Moderate | NA | Imprecise | Direct | Low | Possibly effective Single RCT Magnitude of clinically important effects unclear
Ear plugs or water restrictions in children with TT | Average rate of otorrhea
Ear plugs or water restrictions in children with TT | Average rate of otorrhea | Nonswimming vs. no precautions | High | NA | Imprecise | Direct | Low | No effect Single RCT
Ear plugs or water restrictions in children with TT
Ear plugs or water restrictions in children with TT | Risk of one or more episodes of otorrhea | Ear plugs vs. no precautions | High | Consistent | Imprecise | Direct | Low | Not effective 4 NRCSs OR 1.7 (CrI: 0.9, 3.1)
Ear plugs or water restrictions in children with TT | Risk of one or more episodes of otorrhea
Ear plugs or water restrictions in children with TT | Risk of one or more episodes of otorrhea | Nonswimming vs. no precautions | High | Mostly consistent | Imprecise | Direct | Low | Not effective 6 NRCSs OR 1.52 (CrI: 0.7, 3.2)
Key Question 5
Treatment of TT otorrhea | | Topical antibiotic-glucocorticoid drops vs. watchful waiting | Moderate | Consistent | Somewhat imprecise | Mix of direct and indirect from network MA | Moderate | Network MA of 7 studies Effective: OR 12.0 (CrI: 1.9, 82.0)
Treatment of TT otorrhea
Treatment of TT otorrhea | | Topical antibiotic drops vs watchful waiting | Moderate | Consistent | Somewhat imprecise | Mix of direct and indirect from network MA | Moderate | Network MA of 7 studies Effective: OR 7.2 (CrI: 1.2, 51.0)
Treatment of TT otorrhea
Treatment of TT otorrhea | | Topical antibiotic-glucocorticoid drops vs. oral antibiotics | Moderate | Consistent | Somewhat imprecise | Mix of direct and indirect from network MA | Moderate | Network MA of 10 studies Effective: OR 5.3 (CrI: 1.2, 27.0)
Treatment of TT otorrhea
Treatment of TT otorrhea | | Topical antibiotic vs. oral antibiotics | Moderate | Consistent | Imprecise | Mix of direct and indirect from network MA | Insufficient | Network MA of 10 studies OR 3.3 (CrI: 0.75, 16.0)
Treatment of TT otorrhea
Treatment of TT otorrhea | Quality of Life | | Moderate | NA | Imprecise | Direct | Insufficient | Single RCT

CrI= Credibility Interval; MA = meta-analysis; OR = odds ratio; dB = decibel, MEE= middle ear effusion; TT=Tympanostomy Tubes; MEE= Middle Ear Effusion; RCT= Randomized Control Trial, NRCS=Nonrandomized Comparative Study

## Limitations

The available evidence base is composed of studies that evaluate multiple interventions. Several of these, such as myringotomy alone and oral antibiotic prophylaxis, are rarely used in current practice. Thus, the direct evidence relating to the comparisons of interest must rely on a smaller subset of studies or be augmented with indirect evidence from network meta-analysis.

Many of these trials were performed prior to widespread use of conjugate pneumococcal vaccines and in an era where antibiotic resistance was less common. It is unclear whether these or other factors affect the relative (current vs. historical) benefits of TT placement for recurrent AOM.

With the exception of two trials ^36, 49^ that included children with chronic MEE or recurrent AOM, most enrolled predominately children with chronic MEE. The degree to which patients in clinical practice may have both chronic MEE and recurrent AOM is unclear.

In general, individual studies did not explore treatment effect heterogeneity across subgroups of children by age, sex, clinical history, or sociodemographic factors. Further, we were not able to conduct meaningful subgroup analyses across studies, because most trials used similar inclusion criteria, and thus were not highly variable in terms of the proportions of age, sex, clinical indications, or other baseline characteristics, and because reporting of information on sociodemographic risk factors was sparse and inconsistent.

The generalizability of results to infants and young toddlers and to school age children is also uncertain, given that children in these age groups are underrepresented in available trials.

With the exception of a few NRCSs, patients with cleft palate and Down syndrome have been systematically excluded from comparative trials, limiting the applicability of the evidence for these and other similar subgroups, who experience a higher burden of middle ear disease. Similarly, patients at increased risk of developmental or behavioral sequelae from middle ear disease have not been included (or at least identified) in trials to date.

Across RCTs included in KQs 1 and 2, there was universal lack of blinding of participants, and in many cases of outcome assessors, suggesting a higher risk for ascertainment (measurement) bias, especially for subjective, patient-reported outcomes. Given the intervention in question, placement of a tube in a visible anatomic structure, blinding of participants is not easily accomplished. In addition many studies are at risk for attrition bias, due to dropouts and incomplete followup.

Our meta-analysis of hearing levels used average pure tone hearing levels (typically reported as an average over frequencies of 500, 1000, 2000 and 4000 Hz). This simple measurement is likely insufficient to fully elucidate the complex relationships between hearing and speech perception and development in children.

Assessment of the effectiveness of TT in children with recurrent acute otitis media is particularly challenging, since an episode of AOM in control children (with intact tympanic membrane) results in otalgia and inflammatory changes, whereas children with a functioning TT may present with varying degrees of otorrhea. Bacterial cultures performed in the setting of research may assist in differentiating infections due to organisms associated with AOM from superinfections or colonization with other organisms (e.g. Staphylococcus or Pseudomonas species). Intermediate, outcomes which rely on simple counts or rates of otorrhea, fail to account for the variable character of otorrhea with respect to duration, character, and patient impact. For example, otorrhea may be transient (of little to no concern), recurrent (of more concern, but usually readily managed), or chronic (of considerable concern and difficult to manage).

Our network meta-analysis of the effectiveness of treatments for otorrhea combines trials of fluoroquinolones with other non FDA approved preparations. This presumes equivalent effectiveness and does not consider variable side effects, such as ototoxicity, which may be associated with some agents.

## Future Research Recommendations

Current indications for TT placement largely reflect the inclusion criteria used in clinical trials. Well-validated prognostic models are urgently needed to further stratify the risk of individual children with regard to persistence of middle ear effusion or recurrent AOM.

Pragmatic trials are needed, particularly in children with recurrent AOM, but also in children with chronic MEE or some combination of both. There should be an emphasis on exploring treatment effect heterogeneity, i.e. differential effects of interventions in populations at different risk levels for outcomes of interest. Of specific interest is information on the effects of interventions among higher risk groups, such as patients with cleft palate, Down syndrome, and children with neurodevelopmental disorders.

Since TTs are no longer effective after extrusion, future trials should record per-ear and per-patient outcomes conditional on whether the TT has been extruded and conduct appropriate analyses to estimate the causal effects of TTs among children who still have TTs in place. An analogous observation is that, in trials comparing nonsurgical and surgical interventions, interpretation of findings by intention to treat analyses are often complicated by the high cross-over rates from nonsurgical interventions, such as watchful waiting to surgical ones such as TTs.

Outcome assessment in children with recurrent acute otitis media is challenging, since an episode of AOM in children with an intact tympanic membrane results in otalgia and inflammatory changes, whereas children with a functioning TT exhibit otorrhea. Reliance on outcomes based on simple counts or rates of otorrhea fail to account for the variable character of otorrhea, which can be transient (of little to no concern), recurrent (of more concern, but usually readily managed), or chronic (of considerable concern and difficult to manage). Future trials would benefit from standardization and consistent definition of adverse events. In some cases, e.g. premature extrusion, one author’s premature extrusion may be another’s time extrusion, depending on the duration of anticipated need.^204^

Bacteriologic evaluations performed in the research setting may assist in differentiating otorrhea resulting from infection with organisms associated with AOM (e.g. Streptoccus pneumoniae, nontypable Haemophilus influenza) from superinfections with organisms associated with chronic otorrhea (e.g. Staphylococcus aureus and Pseudomonas aeruginosa).^205^

## Conclusions

Overall, the evidence suggests that TT placed in children with persistent middle-ear effusion result in short term improvements in hearing compared to watchful waiting. However, there is no evidence of a sustained benefit.

Our network meta-analysis of hearing thresholds suggests the possibility of a more sustained improvement in hearing thresholds in at least some children who undergo adenoidectomy and TT placement. A nuanced understanding of which children may benefit from adenoidectomy is limited by the small evidence base and our use of aggregate data.

The evidence suggests that TT did not improve cognition, behavior, or quality of life. However, the evidence if sparse, and prevents any definitive conclusions. The results apply to otherwise healthy children without baseline disorders or delays in language, cognition, or and provide little guidance for the treatment of children who may be at increased risk for speech, language, or learning problems because of baseline sensory, physical, cognitive or behavioral factors.

Children with recurrent AOM may have fewer episodes after TT placement, but the evidence base is severely limited. It is unclear whether quality of life outcomes are improved. The benefits of TT placement must be weighed against a variety of adverse events associated with TT placement.

In children in whom TT have been placed, there is no compelling evidence for the need to either avoid swimming or bathing or use ear plugs or bathing caps

Should otorrhea develop, the available evidence supports treatment of TT otorrhea with a topical antibiotic or antibiotic-glucocorticoid drop.

a As seen in: van Dongen TM, van der Heijden GJ, Venekamp RP, . A trial of treatment for acute otorrhea in children with tympanostomy tubes. N Engl J Med. 2014 Feb 20;370(8):723–33. doi: 10.1056/NEJMoa1301630. PMID: 2455231924552319 . (34 of 75 in watchful waiting arm)

b As seen in: Heslop A, Lildholdt T, Gammelgaard N, . Topical ciprofloxacin is superior to topical saline and systemic antibiotics in the treatment of tympanostomy tube otorrhea in children: the results of a randomized clinical trial. Laryngoscope. 2010 Dec;120(12):2516–20. doi: 10.1002/lary.21015. PMID: 2097910020979100 . (12/26 cured in saline rinse (placebo) arm)

c As seen in: van Dongen TM, van der Heijden GJ, Venekamp RP, . A trial of treatment for acute otorrhea in children with tympanostomy tubes. N Engl J Med. 2014 Feb 20;370(8):723–33. doi: 10.1056/NEJMoa1301630. PMID: 2455231924552319 . (43 of 77 cured in oral antibiotic arm)

d As seen in: Goldblatt EL, Dohar J, Nozza RJ, . Topical ofloxacin versus systemic amoxicillin/clavulanate in purulent otorrhea in children with tympanostomy tubes. Int J Pediatr Otorhinolaryngol. 1998 Nov 15;46(1–2):91–101. PMID: 1019070910190709 . (101 of 146 cured in oral antibiotic arm)