# Appendix I Network Meta-Analysis Model, Inconsistency Analysis Results, and Illustrative Trace and Posterior Density Plots

The meta-analysis models used in this report are described here in a technical manner. We describe the network meta-analysis model, noting that the simple meta-analysis model is a special case of the network model, setting the number of treatments (nodes) to 2.

## Network Meta-Analysis Model

The network meta-analysis model is a hierarchical model that has an observational and a structural part (model).

### Observational Model

y_kj_ ~ N(μ_kj_, σ^2^_kj_), and

μ_kj_ = μ_k_ + XT_k_,

with k = 1,…, K indexing the K studies, and j = 1, 2,… indexing treatment arms. y_kj_ is the mean of the modeled continuous outcome in arm j of study k. X is a design matrix corresponding arms to treatment effects. T_k_ = (T_k1_,…, T_k,N−1_)′ is a column vector of study-specific treatment effects for the N−1 treatments versus a reference treatment, which is chosen arbitrarily. μ_k_ is the mean in study k for the reference treatment.

### Structural Model

Between studies, the study-specific treatment effects are modeled with a multivariate normal distribution

T_k_ ~ N(T,Ω),

where Ω is a compound symmetry matrix of dimension N−1, with all diagonal elements equal to τ^2^ and all off diagonal elements equal to τ^2^ / 2, and T = (T_1_,…, T_N−1_)′ is a column vector of N−1 between-study effect means.

### Hyperparameters

We used normal hyperpriors for means and a uniform prior for standard deviations. Specifically,

T ~ N(0,cI) and

τ ~ U(0,m)

where 0 is a column vector of zeros, I a conformal identity matrix and c and m scaling factors that are set to 15 and 5 times the range of observed effects, respectively.

To check for inconsistency we conducted split node analyses. We replaced each treatment effect T_j_,j > 0 that compares the j-th treatment with the baseline one (j = 0), with a direct effect, and an indirect effect, separating the contributions of head-to-head evidence and indirect evidence and examined whether the difference between them was beyond 0.

## Inconsistency Analysis Results

An ensemble of relevant node-splitting models were generated. Results of direct vs. indirect vs. entire network are plotted below along with inconsistency Bayesian P values for each split comparison.

Appendix Figure I1 Inconsistency analysis results for KQ1 – early hearing levels

A graphical summary of the node-splitting analysis for the comparison of Watchful waiting vs. Myringotomy, presented as a forest plot displaying the mean difference in early hearing level with 95% credible intervals separately for direct evidence, indirect evidence and consistency model. It would appear that the results from the direct and indirect evidence are in agreement with each other and with the results of the consistency model, with a P value of 0.389.

### KQ 1 Late Hearing Levels

There cannot be inconsistency in this network, given that estimates arise from a single trial with three arms.

Appendix Figure I2 Inconsistency analysis results for KQ1 – duration of middle ear effusion

A graphical summary of the node-splitting analysis for three comparisons; Myringotomy & Adenoidectomy vs. Myringotomy, Tympanostomy & Adenoidectomy vs. Myringotomy, and Watchful waiting vs. Myringotomy, presented as a forest plot displaying the mean difference in duration of middle ear effusion with 95% credible intervals, separately for direct evidence, indirect evidence and consistency model. It would appear that the results from the direct and indirect evidence are in agreement with each other and with the results of the consistency model, with P values of 0.304, 0.532 and 0.863 respectively.

Appendix Figure I3 Inconsistency analysis results for KQ5

A graphical summary of the node-splitting analysis for three comparisons; Antibiotic drops vs. Antibiotic-glucocorticoid drop, oral antibiotic vs. Antibiotic-glucocorticoid drops, and Watchful waiting or placebo vs. Antibiotic-glucocorticoid drops, presented as a forest plot displaying the mean odds ratios with 95% credible intervals, separately for direct evidence, indirect evidence and consistency models. It would appear that the results from the direct and indirect evidence are in agreement with each other and with the results of the consistency model, with a P value of 0.451, 0.511 and 0.497 respectively.

Appendix Figure I4 Illustrative trace and posterior density plot for KQ5 network meta-analysis

A two column graphical summary of MCMC estimation of the posterior distribution of the posterior consistency estimates for two illustrative odds ratios for comparisons (Antibiotic-glucocorticoid vs. Watchful waiting or placebo and Oral antibiotic vs. Oral antibiotic & oral glucocorticoid and for the posterior standard deviation. In the left hand column is a time series (trace plot), showing good mixing of MCMC chains after a burn-in of 5000 iterations. On the right are illustrative kernel density plots illustrate that for the first comparison, most of the posterior density is less than zero, supporting improved efficacy, whereas the posterior density is centered near 1 (the null effect), but is imprecisely estimated. The posterior standard deviation is notably right skewed.