# Appendix H Harms

Table H1 Evidence map of studies reporting adverse events

Author PMID Country | Design (Recruitment period) | Tube Type [arm description] | Perioperative Complications | Otorrhea | Tube Blockage | Granulation Tissue | Premature Extrusion | TT Displacement | Persistent Perforation | Myringosclerosis | Atrophy\|Atelectasis\|Retraction | Cholesteotoma | Hearing Loss
Ah-Tye 11389239 US | prosp cohort (1992–1996) | Teflon, Armstrong-type tube | | X
Ahmet 11271428 Turkey | prosp cohort (1988–1997) | Paparella type-1, type-2, Shepard Grommet or Modified T tympanostomy tubes | | | | | | | | X
Allen 16156910 US | prosp cohort (9/2001–11/2001) | Sheehy (0.12 cm diameter) tube | | | X
Baarle 1169745 Netherlands | prosp cohort | Double-flanged, Silastic tubes (Richards) | | | | | X | | X
Barfoed 7190819 Denmark | prosp cohort (nr) | nr | | | | | | | X | X | X | X
Bernard 1991 1861917 Canada | prosp rct (nr) | Reuter bobbin, Richart “T” | | X | | X | | | X | X
Birck 1267356 US | prosp cohort (1972–1974) | nr | | | X | X | | X | X | X | | X
Bonding 4215997 US | cohort (1967–1969) | nr | | | | | | | | | X | X
Bonding 4702615 Denmark | cohort | grommets | | | | | | | | | X
Brodsky 10591365 US | prosp cohort (1998–1999) | nr | X | X | X
Brown 8231117 US | cohort | Goode T-tubes | | X | | | X | | X | | | | X
Cannon 11797262 US | nrcs | Ultracil tube | | X
Cannon 11797262 US | nrcs | Silastic tubes | | X
Carignan 17049144 Canada | prosp cohort (2003–2004) | Goode T-tubes | | | | | | | X
Casselbrant 1565551 US | prosp rct (1981–1988) | Teflon Armstrong-type TT | | | | | | | X
Costa 3472336 Brazil | prosp cohort | nr | | | | | | | X | | | | X
Daly 12759263 US | prosp cohort (1987–1990) | nr | | | | | X | | X | X | X | | X
Daly 9738746 US | cross-sectional (1979–1985) | [adolescents and young adults treated with TT] | | | | | | | | | X | | X
Daly 9738746 US | cross-sectional (1985–1990) | [children treated with TT] | | | | | | | | X | X | | X
De Beer 15224825 Netherlands | prosp cohort (1982–1983) | nr | | | | | | | X | X
De Beer 16151352 Netherlands | prosp ncrs | [positive history of otitis media and ventilation tube insertion] | | | | | | | X | X | X
Debruyne 3177616 Belgium | prosp cohort | nr | | X | | | | | X
Debruyne 3799183 Belgium | cohort | nr | | X | | | | | X
Debruyne 8336923 Belgium | prosp cohort (nr) | Sheppard tube | | X
Djurhuus 25724629 Denmark | retro cohort (1997–2011) | nr | | | | | | | | | | X
Djurhuus 25724629 Denmark | retro cohort (1997–2011) | various [data from National Registers | | | | | | | | | | X
Dohar 16880248 US | prosp rct (2003–2004) | [underwent tympanostomy] | | | X
Eliachar 6613541 Israel | prosp cohort (1975–1981) | Goode long-term T-shaped silicone design tubes | | | X | X | X | | X | | X | X
Fiebach 3570884 Germany | prosp cohort (1979–1984) | nr | | | | | | X | X | X
Fior 6526581 Italy | prosp cohort (1968–1978) | Shepard type | | | | | | X | X | | X
Florentzson 22648089 Sweden | prosp cohort (1/1996–12/1996) | Tympovent 0.9 mm diameter straight fluoroplastic tube from Atos Medical | | | | | | | X
Friedman 11551611 US | prosp cohort | nr | | | | | | | | X
Gates 2492178 US | prosp rct | Shepard-type | | X
Gates 2492178 US | prosp rct | Shepard-type [adenoidectomy + TT] | | X
Gates 3128752 US | prosp cohort (1980–1986) | Shepard-type tube (1.1 mm inner diameter)[TT & Adenoidectomy] | | X
Gates 3128752 US | prosp cohort (1980–1986) | Shepard-type tube (1.1 mm inner diameter)[TT] | | X
Gates 3683478 US | prosp rct (1980–1984) | Shepherd tubes [TT and TT+ adenoidectomy arms] | | X | | | | X | X | | | X
Golz 10187945 US, Israel | retro cohort (1980–1994) | 93% standard polyethylene tubes, 7% Goode T tubes | | X | | | | | X
Golz 10406312 Israel | retro cohort (1978–1997) | “homemade” polyethylene tubes in 5143 ears, Goode T-tubes in 432 ears | | | | | | | | | | X
Gourin 10208683 US | prosp cohort (1995–1997) | Silver oxide-impregnated Sheehy-type tympanostomy tubes | | X
Gundersen 1267702 Norway | prosp cohort | polyethylene ventilating tube | | | | | | | | X | | X | X
Håkansson 25554572 Sweden | prosp cohort (1996–2006) | nr [TT]
Hammaren-Malmi 17582514 Finland | prosp cohort (2001–2002) | nr | | | | | X
Hampton 9118580 Ireland | prosp cohort | Armstrong ventilation tubes | | | | | | | X
Heaton 8877228 UK | prosp cohort (1986–1988) | nr | | X | | | X | | | | | X
Hoffman 12220208 US | prosp/retro cohort | nr | X
Hormann -Iowa-Kollectiv 1816937 Germany | prosp nrcs | [cleft palate - University of Hamburg] | | X | | | | | X | | X | X
Hormann -Iowa-Kollectiv 1816937 Germany | prosp nrcs | [cleft palate - University of Hamburg] | | | | | | | X | | | X
Ida 19324425 US | prosp cohort | pressure equalization tube | | X | | | X
Ingels 16429748 Netherlands | prosp rct (1996–1997) | Bevel Bobbins, Entermed BV, The Netherlands [TT] | | X
Isaacson 18722211 US | prosp cohort (1997–2007) | Armstrong beveled grommet tube | X | | X | | | | | | | | X
Jamal 7543180 Saudi Arabia | prosp ncrs | [TT] | | | X
Jamal 7543180 Saudi Arabia | prosp ncrs | [TT + xylometazoline hydrochloride] | | | X
Jung 19715725 Korea | cohort (2004–2008) | nr | | X
Khan 16773972 Pakistan | prosp cohort (2001–2003) | nr | | | | | X | | X | X
Kinnari 20122337 Finland | prosp rct (2001–2002) | Xomed Soileau Tytan | | X | X | X | X | X | X | | | X
Kokko 1267359 Finland | cohort (1965–1971) | nr | | | | | X | X | X | | | X
Kujala 22466327 Finland | prosp rct (2002–2004) | Donaldson silicone tubes | X
Levine 8179266 US | prosp cohort | Donaldson, Shephard, Paparella or Reuter/bobbin | | | | | | | X
Levinson 6819525 US | prosp cohort | | | X | | X
Li 10547462 US | prosp cohort (1987–1991) | Donaldson tubes, Reuter Bobbin tubes, Shepard tubes or other | | | | | | | | | X
Luo 25465449 China | prosp nrcs (2011–2012) | [tympanostomy tube insertion] | | X | X | X | | | | X | | X
Mackenzie 6541254 UK | prosp cohort (1978–1980) | Pappas 1974, Shah 1971 (Exmoor 142, Shepard 137, Bobbin 132, Arrow 58, Shah 131, Armstrong 138, Colar Button 141, Paparella 60) | | | X | | | X | X | X | | | X
MacKinnon 4105168 UK | prosp cohort (1965–1971) | nr | | | | | X | | X | | | X
Mandel 2789777 US | prosp rct (1979–1984) | Teflon Armstrong-type TT | | | | | | | X
Mandel 8085732 US | prosp cohort (1979–1990) | Teflon Armstrong-type | | X
Marzouk 22183900 US | prosp cohort (2009–2010) | nr | | X
Maw 10459904 UK | prosp rct | [TT after 9 months of watchful waiting]
Maw 10459904 UK | prosp rct | [TT within 6 weeks]
Moore 2396808 Australia | cohort | collar-button or Shephard
Muenker 6778334 Germany | prosp cohort (1966–1978) | nr | | | | X | | X | X | | | X
O’Niel 26115935 US | prosp cohort (2009-nr) | various, including Sheehy, Armstrong, T tube, Activent | | | | | | | X | | X | X
O’Reilly 18594333 US | prosp cohort | nr | | X
Owen 8436453 US | prosp cohort | Armstrong bevelled tube | | X | | | | | | | | | X
Paradise 11309632 US | prosp rct (1991–1995) | Armstrong [TT late treatment; underwent TT insertion 6–9 months after initiaition of symptoms] | | | | X | | | X | X | X
Paradise 11309632 US | prosp rct (1991–1995) | Armstrong [TT early treatment; underwent TT insertion at initiaition of symptoms] | | | | X | | | X | X | X
Paradise 2181158 US | prosp rct/nrcs (1971–1985) | [TT]
Paradise 2181158 US | prosp rct/nrcs (1971–1985) | [TT & Adenoidectomy] | | | | | X | | | | | X
Pereira 16446953 Brazil | prosp cohort (2001–2002) | Short-term ventilation tubes, made of silicone, measuring 1.2 × 2.6 mm, type Donaldson | | X | | | | | X | X | X | X
Plotkin 7195446 US | prosp cohort (1977–1979) | Castelli membrane, Donaldson design, silicone tube (Xomed XO-1201) | | X | | X | | | X
Poetker 17178938 US | prosp rct (2002–2003) | Teflon-coated, fluoroplastic Armstrong beveled TT [receiving ofloxacin otic drops] | | X
Poetker 17178938 US | prosp rct (2002–2003) | Teflon-coated, fluoroplastic Armstrong beveled TT [no postoperative otic drop prophylaxis] | | X
Poetker 17178938 US | prosp rct (2002–2003) | Teflon-coated, fluoroplastic Armstrong beveled TT [receiving neomycin sulfate-polymyxin B sufate-hydrocortisone otic drops] | | X
Postma 9350484 US | prosp cohort (1988–1991) | Amstrong grommt or straight Armstrong | | | | | | | X
Powell 25598389 UK | prosp cohort (2004–2005) | nr | | X | X | | | | X | | X | X
Praveen 15992470 UK | prosp cohort (1998–2003) | Shah ventilation tubes | | | | | X | | | | X
Rakover 9176804 Israel | nrcs | T tube, Paparella TT [TT: no ear drops] | | | | | | | | | | | X
Rakover 9176804 Israel | nrcs | T tube, Paparella TT [TT with ear drops (preventive dexamethasone, neomycin and polymxin B)] | | | | | | | | | | | X
Roland 14702493 US, Canada | prosp rct | nr | | | X
Roos 2128487 Sweden | prosp cohort | polyethylene | | X
Rosenfeld 10807325 US | prosp cohort (1997–1998) | short-acting grommet-type tubes, designed to extrude spontaneously within 6–18 months | | X
Rothera 4040147 UK | prosp cohort (1980–1982) | Xomed silicone Goode T-Tubes (1.1 mm. internal diameter, 12 mm. length) | | X | | | | | X | | | X
Saki 24303379 Iran | prosp cohort (2009–2011) | nr | | X | X | X | X | X | X | X | X
Siddiqui 9225174 UK | prosp cohort (1987–1992) | Mangat tube (Xomed) | | X | | | | | X
Siegel 12161732 US | prosp nrcs (1998–2000) | Reuter bobbin tubes [underwent Laser Office Ventilation of Ears with Insertion of Tubes (LOVE IT)] | | X
Siegel 12161732 US | prosp nrcs (1998–2000) | Reuter bobbin tubes [underwent standard cold surgical myringotomy and tube placement (M&T)] | | X
Slack 6470572 UK | prosp cohort | Shepard grommet | | | | | | | | X
Smillie 25171763 Scotland | nrcs (2002–2012) | [cleft lip palate; underwent VT insertion] | | X | X | X | | | X | X | X | X
Smillie 25171763 Scotland | nrcs (2002–2012) | [no cleft lip palate; underwent VT insertion] | | X | X | X | | | X | X | X | X
Spielmann 18047760 UK | prosp cohort (2003–2004) | nr [second cohort] | | X | X | | X | | | | | | X
Spielmann 18047760 UK | prosp cohort (2000–2000) | nr [first cohort]
Spilsbury 23737350 Austalia | retro cohort (1980–2009) | nr | | | | | | | | | | X
Suetake 2239252 Japan | prosp cohort (1986–1987) | nr | | X | | | | | X
Tavin 3372141 US | prosp cohort (1982–1985) | various | | X | | X
Tos 3814387 Denmark | prosp cohort (1970–1975) | nr | | | | | | | | X | X | X
Tos 7192477 Denmark | cohort | Armstrong tube | | | | | | | | | | X
Tos 985199 Denmark | prosp cohort | nr | | | | | | | X | X | X | X
Tuli 23119801 India | cohort | nr | | X | | | X | | X | | | | X
Valtonen 10435125 Finland | prosp cohort (1983–1984) | Shah vent Teflon tube, inner diameter 1.1 mm | | X | | X | X | | X
Valtonen 12150521 Finland | prosp cohort (1983–1984) | Shah vent Teflon tube, inner diameter 1.1 mm | | | | | | | X | | X
Valtonen 16094135 Finland | prosp cohort (1983–1993) | Shah vent Teflon tube (Xomed) | | X | | | | | X | | X
Van Cauwenberge 576016 Belgium | prosp cohort | nr | | | | | | | X
van Dongen 23874870 Netherlands | retro cohort (2009–2011) | nr | | X
van Heerbeek 16510637 Netherlands | prosp rct (2000–2002) | fluoroplastic, Bevel Bobbin-type TTs (TympVent)
van Heerbeek 16510637 Netherlands | prosp rct (2000–2002) | fluoroplastic, Bevel Bobbin-type TTs (TympVent) [pneumococcal vaccination]
Velepic 21397957 Croatia | prosp rct (2004–2009) | nr | | | | | | | X | X | X
Walker 9287928 Australia | prosp cohort | Shepard grommet, Shah vent tube, Sheehy collar button vent tube | | X | X | | | | X
Wallace 15533143 UK | prosp rct (2001–2002) | Shepard or T tube | | X | X | | X
Weigel 2645490 US | prosp cohort (1983–1984) | Goode T-tubes, Armstrong Teflon, Reuter-Bobbin Stainless Steel, Shepard Teflon | | X | X | | | | X

Table H2 Perioperative complications

Author PMID Country | Design (recruitment period) | Tube Type [arm desc.] | Age (SD) [min, max] | % male | %rAOM [%COME] | Followup | N [ears] | % Perioperative Complications | Definition
Brodsky 10591365 US | prosp cohort (1998–1999) | nr | 3.95 (5.09) [0.50, 23.67] | 56.6 | [75.8] | 1 to 3 months | 54 [96] | [1.04%] | ear canal abrasion
Hoffman 12220208 US | prosp/retro cohort | nr | nr | nr | nr | nr | 3198 | 0.81% | intraoperative, including upper airway obstruction, agitation, prolonged recovery, emesis, laryngospasm, desaturation, bradycardia, dysrhythmia, stridor
Isaacson 18722211 US | prosp cohort (1997–2007) | Armstrong beveled grommet tube | [0.11, 21.00] | nr | nr | nr | [10000] | [0.01%] | tympanic membrane tear
Kujala 22466327 Finland | prosp rct (2002–2004) | Donaldson silicone tubes | 16.1(4.) | 58 | 100[0] | 1 year | 200 | 0.00% | Hemorrhage or anesthetic complications

Table H3 Otorrhea

Author PMID Country | Design (recruitment period) | Tube Type [arm desc.] | Age (SD) [min, max] | % male | %rAOM [%COME] | Followup | N [ears] | % Otorrhea | Definition
Ah-Tye 11389239 US | prosp cohort (1992–1996) | Teflon, Armstrong-type tube | 1.37 [0.50, 3.00] | 59.5 | nr | 24 months | 173 | 58.61% | nr
Bernard 1991 1861917 Canada | prosp rct (nr) | Reuter bobbin, Richart “T” | 4.7 | 56.7 | nr | 18 months | 60 | 13.30% | nr
Brodsky 10591365 US | prosp cohort (1998–1999) | nr | 3.95 (5.09) [0.50, 23.67] | 56.6 | [75.8] | 1 to 3 months | 54 [96] | 11.11% | nr
Brown 8231117 US | cohort | Goode T-tubes | nr | nr | nr | 6 months | 168 [328] | 52.38% | infections
Debruyne 3177616 Belgium | prosp cohort | nr | 4.92 | nr | 45.2% [54.8] | until extrusion | 906 [1685] | 14.79% [10.45%] | nr
Debruyne 3799183 Belgium | cohort | nr | 2.70+ | 55.4 | nr | 0.5 to 6 years | 906 [1685] | 14.90% [10.45%] | nr
Debruyne 8336923 Belgium | prosp cohort (nr) | Sheppard tube | nr | 58 | 100% | 1 year | 126 | 10.00% | 3 or more episodes
Gates 2492178 US | prosp rct | Shepard-type | [4.00, 8.00] | 58 | nr | 2 years | 129 | 28.68% | purulent otorrhea >=1 episode
Gates 3128752 US | prosp cohort (1980–1986) | Shepard-type tube (1.1 mm inner diameter)[TT & Adenoidectomy] | [4.00, 8.00] | 60.3 | nr | nr | 155 | 32.26% | purulent liquid was unequivocably present in external auditory canal, regardless of whether a tube was present or not, not ocunting dried secretions or blood clots
Gates 3128752 US | prosp cohort (1980–1986) | Shepard-type tube (1.1 mm inner diameter)[TT] | [4.00, 8.00] | 60.3 | nr | nr | 227 | 22.47% | purulent liquid was unequivocably present in external auditory canal, regardless of whether a tube was present or not, not ocunting dried secretions or blood clots
Golz 10187945 US, Israel | retro cohort (1980–1994) | 93% standard polyethylene tubes, 7% Goode T tubes | 4.20 (1.40) [0.83, 10.00] | 55 | 91 [7.5] | at least 1 year after extrusion or removal | 1360 [2604] | 10.45% | 3 or more episodes
Heaton 8877228 UK | prosp cohort (1986–1988) | nr | 5.00 [1.00, 12.00] | 60.6 | 0 [100] | nr | 127 | 14.17% | discharge via one or both of their tubes
Hörmann 1816937 Germany | prosp nrcs | [cleft palate - University of Hamburg] | 7.43 [5.00, 10.00] | nr | nr | 8 years | 126 [252] | 10.32% | chronic recurring OME through tubes
Ida 19324425 US | prosp cohort | pressure equalization tube | [0.67, 4.00] | nr | 0 [100] | 16 months | 50 | 4.00% | nr
Ingels 16429748 Netherlands | prosp rct (1996–1997) | Bevel Bobbins, Entermed BV, The Netherlands [TT] | 0.14 (0.01) | 58.8 | 0 [100] | 1 year | 93 | 82.80% | nr
Jung 19715725 Korea | cohort (2004–2008) | nr | 4.50 (2.20) [2.00, 7.00] | 65.7 | 0 [100] | 6 to 24 months | 289 | 23.18% | active otorrhea from middle ear cavity through tympanostomy tube
Kinnari 20122337 Finland | prosp rct (2001–2002) | Xomed Soileau Tytan | 4.1[0.5, 15] | 61 | 36[64] | until extrusion or removal | 170[298] | [6.7%] | chronic otorrhea
Levinson 6819525 US | prosp cohort | | [1.00, 11.00+] | nr | nr | 5 months | 64 [124] | [1.61%] | acute otitis media
Luo 25465449 China | prosp nrcs (2011–2012) | [tympanostomy tube insertion] | 4.80 (1.00) [2.00, 8.00] | 50.9 | nr | 2 years | 55 | 32.73% | otorrhea
Mandel 8085732 US | prosp cohort (1979–1990) | Teflon Armstrong-type | 3.60 [0.50, 12.00] | nr | nr | nr | 246 | 50.00% | nr
Marzouk 22183900 US | prosp cohort (2009–2010) | nr | 3.60 (1.80) [0.90, 9.00] | 67.1 | 15.8 [51.3] | 1 year | 79 | 34.18% | nr
O’Reilly 18594333 US | prosp cohort | nr | 2.70 (2.40) [0.25, 17.00] | 55.2 | nr | 6 months | 509 | 70.33% | nr
Owen 8436453 US | prosp cohort | Armstrong bevelled tube | 2.08 [0.42, 4.00] | nr | nr | 6 months | 52 [98] | [28.21%] | nr
Pereira 16446953 Brazil | prosp cohort (2001–2002) | Short-term ventilation tubes, made of silicone, measuring 1.2 × 2.6 mm, type Donaldson | 2.89 (1.54) [0.92, 9.33] | 60 | 69.3 [30.7] | 38 months | 75 [150] | 61.64% | otorrhea at some time
Plotkin 7195446 US | prosp cohort (1977–1979) | Castelli membrane, Donaldson design, silicone tube (Xomed XO-1201) | 5.20 [2.50, 11.00] | 60.7 | 0 [100] | nr | 89 [162] | 12.36% | purulent otitis media and serous otitis media
Powell 25598389 UK | prosp cohort (2004–2005) | nr | 4.60 | nr | nr | 9 weeks to 10 years | 89 | 19.10% | otorrhea at 9 weeks
Rosenfeld 10807325 US | prosp cohort (1997–1998) | short-acting grommet-type tubes, designed to extrude spontaneously within 6–18 months | med 1.40 [0.50, 9.90] | 60 | 56 [42] | 2 to 4 months | 248 | 29.91% | at first postoperative office visit
Rothera 4040147 UK | prosp cohort (1980–1982) | Xomed silicone Goode T-Tubes (1.1 mm. internal diameter, 12 mm. length) | nr | nr | 0 [100] | 30 months | 73 [131] | 20.55% | nr
Saki 24303379 Iran | prosp cohort (2009–2011) | nr | [0.83, 6.00] | 55.8 | 0 [100] | 12 to 18 months | 208 | 17.79% | transient otorrhea; delayed otorrhea; chronic otorrhea non-responsive to medical treatment
Siddiqui 9225174 UK | prosp cohort (1987–1992) | Mangat tube (Xomed) | mode 5.00 [0.50, 14.00] | 61.8 | 0 [100] | 3 years | 191 [322] | 13.09% [11.18%] | had ear discharge on one or more occasions, requiring abx and eardrops
Smillie 25171763 Scotland | nrcs (2002–2012) | [no cleft lip palate; underwent VT insertion] | med 3.50 [0.60, 10.40] | 55 | nr | nr | 60 | 60.00% | nr
Spielmann 18047760 UK | prosp cohort (2003–2004) | nr [second cohort] | 5.30 [0.83, 9.00] | 61.4 | 18.8 [81.2] | 3 months | 84 [195] | 14.29% | nr
Suetake 2239252 Japan | prosp cohort (1986–1987) | nr | 6.20 (2.00) [3.00, 11.00] | 59.6 | 0 [100] | nr | 52 [90] | 47.27% | recurrence of SOM
Tavin 3372141 US | prosp cohort (1982–1985) | various | 4.80 (1.50) [0.33, 16.00] | 63.2 | nr | 365 to 728 days | 95 [187] | [9.09%] | excluding post operative otorrhea
Tuli 23119801 India | cohort | nr | nr | 66.7 | 0 [100] | nr | 100 | 12.00% | excessive bleeding
Valtonen 10435125 Finland | prosp cohort (1983–1984) | Shah vent Teflon tube, inner diameter 1.1 mm | 0.84 [0.42, 1.33] | 58.4 | 34.2 [65.8] | 5 years | 281 [281] | [66.55%] | post-tympanostomy otorrhea during primary ventilation tube
Valtonen 16094135 Finland | prosp cohort (1983–1993) | Shah vent Teflon tube (Xomed) | nr | 51.4 | 0 [100] | 5 to 7.2 years | 72 [124] | 6.94% | ongoing OME
van Dongen 23874870 Netherlands | retro cohort (2009–2011) | nr | 4.40 (2.30) | 58 | nr | nr | 1184 | 67.00% | one or more episodes in first year after TT placement
Weigel 2645490 US | prosp cohort (1983–1984) | Goode T-tubes, Armstrong Teflon, Reuter-Bobbin Stainless Steel, Shepard Teflon | 3.80 [0.60, 13.00] | 59 | 45 [41] | 21 months | 75 [150] | [35.33%] | nr

Table H4 Tube blockage

Author PMID Country | Design (recruitment period) | Tube Type [arm desc.] | Age (SD) [min, max] | % male | %rAOM [%COME] | Followup | N [ears] | % Tube Blockage | Defintion
Allen 16156910 US | prosp cohort (9/2001–11/2001) | Sheehy (0.12 cm diameter) tube | 4 [0.75, 11.83] | 68.1 | 74 [19.5] | 2 weeks | 112 | 10.71% | nr
Birck 1267356 US | prosp cohort (1972–1974) | nr | nr | 59.2 | nr | 6+ months | 736 [2327] | [2.49%] | tubes occluded
Brodsky 10591365 US | prosp cohort (1998–1999) | nr | 3.95 (5.09) [0.50, 23.67] | 56.6 | [75.8] | 1 to 3 months | 54 [96] | [4.05%] | nr
Dohar 16880248 US | prosp rct (2003–2004) | [underwent tympanostomy] | [0.50, 11.00] | 52.5 | nr | 3 weeks | 39 | 2.56% | device blockage
Eliachar 6613541 Israel | prosp cohort (1975–1981) | Goode long-term T-shaped silicone design tubes | 8.33 [4.50, 16.00] | nr | nr | 8 to 72 months | 122 [203] | [2.96%] | blockage
Isaacson 18722211 US | prosp cohort (1997–2007) | Armstrong beveled grommet tube | [0.11, 21.00] | nr | nr | nr | [10000] | [0.03%] | permanent
Jamal 7543180 Saudi Arabia | prosp ncrs | [TT] | nr | 54.2 | 0 [100] | 3 months | 40 [76] | 17.50% | nr
Kinnari 20122337 Finland | prosp rct (2001–2002) | Xomed Soileau Tytan | 4.1[0.5, 15] | 61 | 36[64] | until extrusion or removal | 170[298] | [37%] | tubes blocked at 9 months
Luo 25465449 China | prosp nrcs (2011–2012) | [tympanostomy tube insertion] | 4.80 (1.00) [2.00, 8.00] | 50.9 | nr | 2 years | 55 | 9.09% | tube blockage
Mackenzie 6541254 UK | prosp cohort (1978–1980) | Pappas 1974, Shah 1971 (Exmoor 142, Shepard 137, Bobbin 132, Arrow 58, Shah 131, Armstrong 138, Colar Button 141, Paparella 60) | 10.80 [0.75, 77.00] | 58.3 | 0 [100] | 2.25 years | 588 [939] | [17.15%] | not patent at 3 month f/u
Powell 25598389 UK | prosp cohort (2004–2005) | nr | 4.60 | nr | nr | 9 weeks to 10 years | 89 | 8.99% | blocked tube at 9 weeks
Roland 14702493 US, Canada | prosp rct | nr | 2.45 [0.50, 12.00] | 62.3 | nr | 18 days | 599 | 0.17% | tube blocakge
Saki 24303379 Iran | prosp cohort (2009–2011) | nr | [0.83, 6.00] | 55.8 | 0 [100] | 12 to 18 months | 208 | 3.85% | obstruction of the VT on the tympanic membrane
Smillie 25171763 Scotland | nrcs (2002–2012) | [no cleft lip palate; underwent VT insertion] | med 3.50 [0.60, 10.40] | 55 | nr | nr | 60 | 1.67% | grommet occlusion-wax
Spielmann 18047760 UK | prosp cohort (2003–2004) | nr [second cohort] | 5.30 [0.83, 9.00] | 61.4 | 18.8 [81.2] | 3 months | 84 [195] | 10.71% | nr
Walker 9287928 Australia | prosp cohort | Shepard grommet, Shah vent tube, Sheehy collar button vent tube | 3.80 | nr | 12 [85] | until extrusion | 106 | [2.83%] | lumenal obstruction
Wallace 15533143 UK | prosp rct (2001–2002) | Shepard or T tube | 6.00 [1.00, 13.00] | 63.6 | 75.8 | 1 month | 26 | [6.52%] | 1 month follow up
Weigel 2645490 US | prosp cohort (1983–1984) | Goode T-tubes, Armstrong Teflon, Reuter-Bobbin Stainless Steel, Shepard Teflon | 3.80 [0.60, 13.00] | 59 | 45 [41] | 21 months | 75 [150] | [37.33%] | temporary or permanent

Table H5 Granulation tissue

Author PMID Country | Design (recruitment period) | Tube Type [arm desc.] | Age (SD) [min, max] | % male | %rAOM [%COME] | Followup | N [ears] | % Granulation Tissue | Defintion Granulation Tissue
Bernard 1991 1861917 Canada | prosp rct (nr) | Reuter bobbin, Richart “T” | 4.7 | 56.7 | nr | 18 months | 60 | 3.3 | purulent discharge and granuloma formation
Birck 1267356 US | prosp cohort (1972–1974) | nr | nr | 59.2 | nr | 6+ months | 736 [2327] | [0.17%]
Eliachar 6613541 Israel | prosp cohort (1975–1981) | Goode long-term T-shaped silicone design tubes | 8.33 [4.50, 16.00] | nr | nr | 8 to 72 months | 122 [203] | [5.91%] | local granuloma
Kinnari 20122337 Finland | prosp rct (2001–2002) | Xomed Soileau Tytan | 4.1[0.5, 15] | 61 | 36[64] | until extrusion or removal | 170[298] | [20.1%] | nr
Levinson 6819525 US | prosp cohort | | [1.00, 11.00+] 4.80 | nr | nr | 5 months | 64 [124] | [5.65%] | granulations and discharge
Luo 25465449 China | prosp nrcs (2011–2012) | [tympanostomy tube insertion] | (1.00) [2.00, 8.00] | 50.9 | nr | 2 years | 55 | 12.73% | granulation formation
Muenker 6778334 Germany | prosp cohort (1966–1978) | nr | nr | nr | nr | nr | 631 [1060] | [1.79%]
Plotkin 7195446 US | prosp cohort (1977–1979) | Castelli membrane, Donaldson design, silicone tube (Xomed XO-1201) | 5.20 [2.50, 11.00] | 60.7 | 0 [100] | nr | 89 [162] | [1.85%] | polypoid granulations fromed around the tube
Saki 24303379 Iran | prosp cohort (2009–2011) | nr | [0.83, 6.00] | 55.8 | 0 [100] | 12 to 18 months | 208 | 3.37% | nr
Smillie 25171763 Scotland | nrcs (2002–2012) | [no cleft lip palate; underwent VT insertion] | med 3.50 [0.60, 10.40] | 55 | nr | nr | 60 | 1.67%
Tavin 3372141 US | prosp cohort (1982–1985) | various | 4.80 (1.50) [0.33, 16.00] | 63.2 | nr | 365 to 728 days | 95 [187] | [2.14%] | resulted in granuloma formation between 90 and 183 days
Valtonen 10435125 Finland | prosp cohort (1983–1984) | Shah vent Teflon tube, inner diameter 1.1 mm | 0.84 [0.42, 1.33] | 58.4 | 34.2 [65.8] | 5 years | 281 [281] | [5.69%]

Table H6 Premature extrusion

Author PMID Country | Design (recruitment period) | Tube Type [arm desc.] | Age (SD) [min, max] | % male | %rAOM [%COME] | Followup | N [ears] | % Premature Extrusion | Definition Premature Extrucsion
van Baarle 1169745 Netherlands | prosp cohort | Double-flanged, Silastic tubes (Richards) | nr | nr | nr | 12+ weeks | 60 | 13.33%
Brown 8231117 US | cohort | Goode T-tubes | nr | nr | nr | 6 months | 168 [328] | 0.00% | premature extrusion
Daly 12759263 US | prosp cohort (1987–1990) | nr | [0.50, 8.00] | 61 | nr | 3 to 8 years | 138 [275] | [56.00%] | nr
Eliachar 6613541 Israel | prosp cohort (1975–1981) | Goode long-term T-shaped silicone design tubes | 8.33 [4.50, 16.00] | nr | nr | 8 to 72 months | 122 [203] | 81.82% | extruded spontaneously
Hammaren-Malmi 17582514 Finland | prosp cohort (2001–2002) | nr | 1.90 [1.00, 4.00] | 54 | nr | 12 months | 217 | 73.74% | tympanostomy tube lost or non-patent during follow-up (12 months)
Heaton 8877228 UK | prosp cohort (1986–1988) | nr | 5.00 [1.00, 12.00] | 60.6 | 0 [100] | nr | 127 | 34.65% | undergone insertion of a subsequent tube or tubes
Ida 19324425 US | prosp cohort | pressure equalization tube | [0.67, 4.00] | nr | 0 [100] | 16 months | 50 | 58.00% | nr
Khan 16773972 Pakistan | prosp cohort (2001–2003) | nr | [2.00, 40.00] | 66.6 | 0 [100] | 18 to 24 months | 57 [114] | [0.88%] | nr
Kinnari 20122337 Finland | prosp rct (2001–2002) | Xomed Soileau Tytan | 4.1[0.5, 15] | 61 | 36[64] | until extrusion or removal | 170[298] | [3.9%] | within 3 months
Kokko 1267359 Finland | cohort (1965–1971) | nr | nr | nr | nr | 3.167 years (average) | [290] | [0.24%] | nr
MacKinnon 4105168 UK | prosp cohort (1965–1971) | nr | =<16.00 | nr | nr | nr | 95 [165] | 37.89% [39.39%] | m requiring grommets on ore than one occassion
Paradise 2181158 US | prosp rct/nrcs (1971–1985) | [TT & Adenoidectomy] | nr | 67 | nr | nr | 97 | [5.60%] | perforations remaining unhealed for periods of 10 months to 4.5 years
Praveen 15992470 UK | prosp cohort (1998–2003) | Shah ventilation tubes | 5.00 [1.60, 14.50] | 64 | nr | nr | 606 [1174] | 8.42% | early extrusions
Saki 24303379 Iran | prosp cohort (2009–2011) | nr | [0.83, 6.00] | 55.8 | 0 [100] | 12 to 18 months | 208 | 5.77% | early extrusion from the membrane
Spielmann 18047760 UK | prosp cohort (2003–2004) | nr [second cohort] | 5.30 [0.83, 9.00] | 61.4 | 18.8 [81.2] | 3 months | 84 [195] | 10.71% | nr
Tuli 23119801 India | cohort | nr | nr | 66.7 | 0 [100] | nr | 100 | 4.00% | early dislocation of grommet
Valtonen 10435125 Finland | prosp cohort (1983–1984) | Shah vent Teflon tube, inner diameter 1.1 mm | 0.84 [0.42, 1.33] | 58.4 | 34.2 [65.8] | 5 years | 281 [281] | [1.78%] | ventilation tube extruded early, within two weeks postoperatively
Wallace 15533143 UK | prosp rct (2001–2002) | Shepard or T tube | 6.00 [1.00, 13.00] | 63.6 | 75.8 | 1 month | 26 | [4.35%] | 1 month

Table H7 TT displacement

Author PMID Country | Design (recruitment period) | Tube Type [arm desc.] | Age (SD) [min, max] | % male | %rAOM [%COME] | Followup | N [ears] | % TT Displacement | Definition TT displacement
Birck 1267356 US | prosp cohort (1972–1974) | nr | nr | 59.2 | nr | 6+ months | 736 [2327] | [0.60%] | tubes in tympanum
Fiebach 3570884 Germany | prosp cohort (1979–1984) | nr | [1.00, 6.00] | 60.5 | nr | nr | 534 [1000] | 0.37% | nr
Fior 6526581 Italy | prosp cohort (1968–1978) | Shepard type | 3.00 [0.33, 6.00] | 60.6 | 100 [0] | 5 to 15 years | 61 [108] | [0.93%] | Migration of the tube into the tympanic cavity
Kinnari 20122337 Finland | prosp rct (2001–2002) | Xomed Soileau Tytan | 4.1[0.5, 15] | 61 | 36[64] | until extrusion or removal | 170[298] | 0.00% | nr
Kokko 1267359 Finland | cohort (1965–1971) | nr | nr | nr | nr | 3.167 years (average) | [290] | [0.69%] | slippage of TT into tympanum
Mackenzie 6541254 UK | prosp cohort (1978–1980) | Pappas 1974, Shah 1971 (Exmoor 142, Shepard 137, Bobbin 132, Arrow 58, Shah 131, Armstrong 138, Colar Button 141, Paparella 60) | 10.80 [0.75, 77.00] | 58.3 | 0 [100] | 2.25 years | 588 [939] | [2.34%] | nr
Muenker 6778334 Germany | prosp cohort (1966–1978) | nr | nr | nr | nr | nr | 631 [1060] | [0.75%] | extrusion into the tympanic cavity
Saki 24303379 Iran | prosp cohort (2009–2011) | nr | [0.83, 6.00] | 55.8 | 0 [100] | 12 to 18 months | 208 | 0.48% | displacement into the middle ear

Table H8 Persistent perforation

Author PMID Country | Design (recruitment period) | Tube Type [arm desc.] | Age (SD) [min, max] | % male | %rAOM [%COME] | Followup | N [ears] | % Persistent Perforation | Definition Persistent Perforation
van Baarle 1169745 Netherlands | prosp cohort | Double-flanged, Silastic tubes (Richards) | nr | nr | nr | 12+ weeks | 60 | 1.67% | perforation remained 2 months later
Barfoed 7190819 Denmark | prosp cohort (nr) | nr | nr | 57 | 0[100] | 4.5 to 7.5 years | 90[173] | nr[5.00%] | central perforations without suppuration
Bernard 1991 1861917 Canada | prosp rct (nr) | Reuter bobbin, Richart “T” | 4.7 | 56.7 | nr | 18 months | 60 | 0.00% | nr
Birck 1267356 US | prosp cohort (1972–1974) | nr | nr | 59.2 | nr | 6+ months | 736 [2327] | 1.90% | nr
Brown 8231117 US | cohort | Goode T-tubes | nr | nr | nr | 6 months | 168 [328] | [2.44%] | perforations persisted in tympanic membranes after extraction
Carignan 17049144 Canada | prosp cohort (2003–2004) | Goode T-tubes | 5.70 | 62 | 71 [29] | 18 months | nr | 1.79% | perforations persisted > 6 months
Casselbrant 1565551 US | prosp rct (1981–1988) | Teflon Armstrong-type TT | nr | 58.1 | 100[0] | 2 years | 86 | 13% | perforation after spontaneous extrusion
Costa 3472336 Brazil | prosp cohort | nr | nr | nr | 0 [100] | nr | 79 | 2.53% | perforation of the eardrum
Daly 12759263 US | prosp cohort (1987–1990) | nr | [0.50, 8.00] | 61 | nr | 3 to 8 years | 138 [275] | [67.64%] | perforation
De Beer 15224825 Netherlands | prosp cohort (1982–1983) | nr | nr | 47 | nr | 18 years | 51 [101] | [5.94%]
De Beer 16151352 Netherlands | prosp ncrs | [positive history of otitis media and ventilation tube insertion] | nr | nr | nr | 16 years | 51[102] | [6.78%] | at 18 years old
Debruyne 3177616 Belgium | prosp cohort | nr | 4.92 | nr | 45.2% [54.8] | until extrusion | 906 [1685] | 1.14% | perforations persisted > 6 months
Debruyne 3799183 Belgium | cohort | nr | 2.70+ | 55.4 | nr | 0.5 to 6 years | 906 [1685] | [1.27%] | perforations persisted > 6 months
Eliachar 6613541 Israel | prosp cohort (1975–1981) | Goode long-term T-shaped silicone design tubes | 8.33 [4.50, 16.00] | nr | nr | 8 to 72 months | 122 [203] | [3.94%] | permanent unhealed perforations
Fiebach 3570884 Germany | prosp cohort (1979–1984) | nr | [1.00, 6.00] | 60.5 | nr | nr | 534 [1000] | [0.94%] | lasting perforation of the tympanic membrane
Fior 6526581 Italy | prosp cohort (1968–1978) | Shepard type | 3.00 [0.33, 6.00] | 60.6 | 100 [0] | 5 to 15 years | 61 [108] | [5.56%] | Persistent perforation of the tympanic membrane following extrusion of the tube
Florentzson 22648089 Sweden | prosp cohort (1/1996–12/1996) | Tympovent 0.9 mm diameter straight fluoroplastic tube from Atos Medical | 3.90 | 61 | nr | 10 years | 155 [280] | [2.1%] | permanent perforations
Golz 10187945 US, Israel | retro cohort (1980–1994) | 93% standard polyethylene tubes, 7% Goode T tubes | 4.20 (1.40) [0.83, 10.00] | 55 | 91 [7.5] | at least 1 year after extrusion or removal | 1360 [2604] | [3.06%]
Hampton 9118580 Ireland | prosp cohort | Armstrong ventilation tubes | [0.75, 10.25] | 58.7 | nr | 17 months (mean) | 109 [218] | [2.75%] | tympanic membrane perforations
Hörmann 1816937 Germany | prosp nrcs | [cleft palate -University of Hamburg] | 7.43 [5.00, 10.00] | nr | nr | 8 years | 126 [252] | 8.73%
Khan 16773972 Pakistan | prosp cohort (2001–2003) | nr | [2.00, 40.00] | 66.6 | 0 [100] | 18 to 24 months | 57 [114] | 2.63% | nr
Kinnari 20122337 Finland | prosp rct (2001–2002) | Xomed Soileau Tytan | 4.1[0.5, 15] | 61 | 36[64] | until extrusion or removal | 170[298] | [0.7%] | nr
Kokko 1267359 Finland | cohort (1965–1971) | nr | nr | nr | nr | 3.167 years (average) | [290] | [1.72%] | dry perforation (central 2–3 mm pars tensa defect); perforation with discharge
Levine 8179266 US | prosp cohort | Donaldson, Shephard, Paparella or Reuter/bobbin | [0.50, 8.00] | nr | 0 [100] | 4 years (mean) | 149 | 14.09% | tympanic membrane perforations
Mackenzie 6541254 UK | prosp cohort (1978–1980) | Pappas 1974, Shah 1971 (Exmoor 142, Shepard 137, Bobbin 132, Arrow 58, Shah 131, Armstrong 138, Colar Button 141, Paparella 60) | 10.80 [0.75, 77.00] | 58.3 | 0 [100] | 2.25 years | 588 [939] | 0.34% | perforation at long term f/u
MacKinnon 4105168 UK | prosp cohort (1965–1971) | nr | =<16.00 | nr | nr | nr | 95 [165] | [3.03%] | perforation after removal of grommets
Mandel 2789777 US | prosp rct (1979–1984) | Teflon Armstrong-type TT | nr | nr | 0[100] | until extrusion | 63[102] | [11.7%] | perforation after spontaneous extrusion
Muenker 6778334 Germany | prosp cohort (1966–1978) | nr | nr | nr | nr | nr | 631 [1060] | [2.45%]
O’Niel 26115935 US | prosp cohort (2009-nr) | various, including Sheehy, Armstrong, T tube, Activent | 3 (2.8) [0.08 – 17′ | 42.4 | 60[38] | 1 year post TT extrusion | 634[544] | 1.10% | post-extrusion performation
Paradise 11309632 US | prosp rct (1991–1995) | Armstrong [TT early treatment; underwent TT insertion at initiaition of symptoms] | 5.00 | 52.6 | 0 [100] | ~2 years | 121 [242] | 4.96% [2.48%] | perforation with or without other abnormality
Pereira 16446953 Brazil | prosp cohort (2001–2002) | Short-term ventilation tubes, made of silicone, measuring 1.2 × 2.6 mm, type Donaldson | 2.89 (1.54) [0.92, 9.33] | 60 | 69.3 [30.7] | 38 months | 75 [150] | [2.05%]
Plotkin 7195446 US | prosp cohort (1977–1979) | Castelli membrane, Donaldson design, silicone tube (Xomed XO-1201) | 5.20 [2.50, 11.00] | 60.7 | 0 [100] | nr | 89 [162] | [2%] | perforation for ≥ 6 months
Postma 9350484 US | prosp cohort (1988–1991) | Amstrong grommt or straight Armstrong | nr | nr | nr | until extruded | 346 | 5.20% | nr
Powell 25598389 UK | prosp cohort (2004–2005) | nr | 4.60 | nr | nr | 9 weeks to 10 years | 89 | 6.67%
Rothera 4040147 UK | prosp cohort (1980–1982) | Xomed silicone Goode T-Tubes (1.1 mm. internal diameter, 12 mm. length) | nr | nr | 0 [100] | 30 months | 73 [131] | [3.82%] | central perforations
Saki 24303379 Iran | prosp cohort (2009–2011) | nr | [0.83, 6.00] mode | 55.8 | 0 [100] | 12 to 18 months | 208 | 2.40%
Siddiqui 9225174 UK | prosp cohort (1987–1992) | Mangat tube (Xomed) | 5.00 [0.50, 14.00] | 61.8 | 0 [100] | 3 years | 191 [322] | [5.28%] | perforation at a year follow-up
Smillie 25171763 Scotland | nrcs (2002–2012) | [no cleft lip palate; underwent VT insertion] | med 3.50 [0.60, 10.40] | 55 | nr | nr | 60 | 5.00% | tympanic membrane perforation
Suetake 2239252 Japan | prosp cohort (1986–1987) | nr | 6.20 (2.00) [3.00, 11.00] | 59.6 | 0 [100] | nr | 52 [90] | [14.55%] | nr
Tos 985199 Denmark | prosp cohort | nr | nr | 14 | nr | 1 to 8 years | 109 | 2.75%
Tuli 23119801 India | cohort | nr | nr | 66.7 | 0 [100] | nr | 100 | 8.00% | permanent perforation
Valtonen 10435125 Finland | prosp cohort (1983–1984) | Shah vent Teflon tube, inner diameter 1.1 mm | 0.84 [0.42, 1.33] | 58.4 | 34.2 [65.8] | 5 years | 281 [281] | [2.49%]
Valtonen 12150521 Finland | prosp cohort (1983–1984) | Shah vent Teflon tube, inner diameter 1.1 mm | 0.84 [0.42, 1.33] | 58.4 | 34.2 [65.8] | 5 years | 281 [281] | [4.63%]
Valtonen 16094135 Finland | prosp cohort (1983–1993) | Shah vent Teflon tube (Xomed) | nr | 51.4 | 0 [100] | 5 to 7.2 years | 72 [124] | 6.94% | nr
Van Cauwenberge 576016 Belgium | prosp cohort | nr | [2.00, 14.00] | 49.3 | 0 [100] | 5 to 120 months | 148 | 2.70%
Velepic 21397957 Croatia | prosp rct (2004–2009) | nr | 5.44 [2.00, 12.00] | nr | 0 [100] | nr | [161] | [0.00%] | eardrum peforation
Walker 9287928 Australia | prosp cohort | Shepard grommet, Shah vent tube, Sheehy collar button vent tube | 3.80 | nr | 12 [85] | until extrusion | 106 | [0.47%]
Weigel 2645490 US | prosp cohort (1983–1984) | Goode T-tubes, Armstrong Teflon, Reuter-Bobbin Stainless Steel, Shepard Teflon | 3.80 [0.60, 13.00] | 59 | 45 [41] | 21 months | 75 [150] | [6.00%]

Table H9 Myringosclerosis

Author PMID Country | Design (recruitment period) | Tube Type [arm desc.] | Age (SD) [min, max] | % male | %rAOM [%COME] | Followup | N [ears] | % Myringosclerosis | def_myringosclerosis
Koc 11271428 Turkey | prosp cohort (1988–1997) | Paparella type-1, type-2, Shepard Grommet or Modified T tympanostomy tubes | nr | 58 | nr | nr | 251 [431] | [49.88%] | nr
Barfoed 7190819 Denmark | prosp cohort (nr) | nr | nr | 57 | 0[100] | 4.5 to 7.5 years | 90[173] | nr[23%] | tympanosclerosis along the whole anulus
Bernard 1991 1861917 Canada | prosp rct (nr) | Reuter bobbin, Richart “T” | 4.7 | 56.7 | nr | 18 months | 60 | 28.3 | localized without involvement of middle ear structures
Birck 1267356 US | prosp cohort (1972–1974) | nr | nr | 59.2 | nr | 6+ months | 736 [2327] | 0.95% | tympanosclerosis (43 tube insertions)
Daly 12759263 US | prosp cohort (1987–1990) | nr | [0.50, 8.00] | 61 | nr | 3 to 8 years | 138 [275] | [49.82%] | myringosclerosis
Daly 9738746 US | cross-sectional (1985–1990) | [children treated with TT] | 17.70 (3.50) [13.00, 28.00] | 61 | 0 [100] | nr | 108 | 61.00% | 8- to 12-year-olds
De Beer 15224825 Netherlands | prosp cohort (1982–1983) | nr | nr | 47 | nr | 18 years | 51 [101] | [64.36%]
De Beer 16151352 Netherlands | prosp ncrs | [positive history of otitis media and ventilation tube insertion] | nr | nr | nr | 16 years | 51[102] | 55.93% | at 18 years
Fiebach 3570884 Germany | prosp cohort (1979–1984) | nr | [1.00, 6.00] | 60.5 | nr | nr | 534 [1000] | [11.29%] | scarring or calcification
Friedman 11551611 US | prosp cohort | nr | [0.08, 30.00] | 60.1 | nr | nr | 81 | 34.57% | tympanosclerosis in at least one ear
Gundersen 1267702 Norway | prosp cohort | polyethylene ventilating tube | 7.50 [1.00, 14.00] | nr | 0 [100] | 2 to 11 years | 100 [196] | [11.22%]
Khan 16773972 Pakistan | prosp cohort (2001–2003) | nr | [2.00, 40.00] 4.80 | 66.6 | 0 [100] | 18 to 24 months | 57 [114] | [5.26%] | nr
Luo 25465449 China | prosp nrcs (2011–2012) | [tympanostomy tube insertion] | (1.00) [2.00, 8.00] | 50.9 | nr | 2 years | 55 | 34.55% | myringosclerosis
Mackenzie 6541254 UK | prosp cohort (1978–1980) | Pappas 1974, Shah 1971 (Exmoor 142, Shepard 137, Bobbin 132, Arrow 58, Shah 131, Armstrong 138, Colar Button 141, Paparella 60) | 10.80 [0.75, 77.00] | 58.3 | 0 [100] | 2.25 years | 588 [939] | 0.68% | tympanosclerosis at long term f/u
Paradise 11309632 US | prosp rct (1991–1995) | Armstrong [TT early treatment; underwent TT insertion at initiaition of symptoms] | 5.00 | 52.6 | 0 [100] | ~2 years | 121 [242] | 3.31% [4.13%] | tympanosclerosis
Pereira 16446953 Brazil | prosp cohort (2001–2002) | Short-term ventilation tubes, made of silicone, measuring 1.2 × 2.6 mm, type Donaldson | 2.89 (1.54) [0.92, 9.33] | 60 | 69.3 [30.7] | 38 months | 75 [150] | [2.74%] | nr
Saki 24303379 Iran | prosp cohort (2009–2011) | nr | [0.83, 6.00] | 55.8 | 0 [100] | 12 to 18 months | 208 | 37.98% | nr
Slack 6470572 UK | prosp cohort | Shepard grommet | [4.00, 10.00] | nr | nr | 21 months | 124 | 56.45% | nr
Smillie 25171763 Scotland | nrcs (2002–2012) | [no cleft lip palate; underwent VT insertion] | med 3.50 [0.60, 10.40] | 55 | nr | nr | 60 | 5.00% | nr
Tos 3814387 Denmark | prosp cohort (1970–1975) | nr | nr | nr | nr | nr | 278 [527] | 33.45% | nr
Tos 985199 Denmark | prosp cohort | nr | nr | 14 | nr | 1 to 8 years | 109 | 22.94% | diffuse tympanosclerosis
Velepic 21397957 Croatia | prosp rct (2004–2009) | nr | 5.44 [2.00, 12.00] | nr | 0 [100] | nr | [161] | [26.09%] | nr

Table H10 Atrophy or atelectasis or retraction

Author PMID Country | Design (recruitment period) | Tube Type [arm desc.] | Age (SD) [min, max] | % male | %rAOM [%COME] | Followup | N [ears] | % Atrophy Atelectasis Retraction | Definition
Barfoed 7190819 Denmark | prosp cohort (nr) | nr | nr | 57 | 0[100] | 4.5 to 7.5 years | 90[173] | [25.00%] | atrophy at the former grommet site, anteriorly
Bonding 4215997 US | cohort (1967–1969) | nr | [=<3.00, 4.00] | 66.7 | 0 [100] | 16 to 48 months | 108 [175] | 13.89% | diffuse atrophy of the tympanic membrane
Bonding 4702615 Denmark | cohort | nr | nr | 66.7 | 0 [100] | nr | 117 [188] | 8.55% | atrophic drum
Daly 12759263 US | prosp cohort (1987–1990) | nr | [0.50, 8.00] | 61 | nr | 3 to 8 years | 138 [275] | [66.18%] | atrophy
Daly 9738746 US | cross-sectional (1985–1990) | [children treated with TT] | 17.70 (3.50) [13.00, 28.00] | 61 | 0 [100] | nr | 108 | 4.00% | severe TM retraction
De Beer 16151352 Netherlands | prosp ncrs | [positive history of otitis media and ventilation tube insertion] | nr | nr | nr | 16 years | 51[102] | 20.34% | atrophy at 18 years
Eliachar 6613541 Israel | prosp cohort (1975–1981) | Goode long-term T-shaped silicone design tubes | 8.33 [4.50, 16.00] | nr | nr | 8 to 72 months | 122 [203] | 100.00% | retraction pockets (75 in the attic, 82 - both in the attic and posterior superior quandrant and 38 had other variations)
Fior 6526581 Italy | prosp cohort (1968–1978) | Shepard type | 3.00 [0.33, 6.00] | 60.6 | 100 [0] | 5 to 15 years | 61 [108] | [5.56%] | tympanic atrophy
Hörmann 1816937 Germany | prosp nrcs | [cleft palate - University of Hamburg] | 7.43 [5.00, 10.00] | nr | nr | 8 years | 126 [252] | 6.35% | retraction and atrophy
Li 10547462 US | prosp cohort (1987–1991) | Donaldson tubes, Reuter Bobbin tubes, Shepard tubes or other | nr | 57 | 0 [100] | 4 to 6 years | 109 [214] | 42.86% | severe pars tensa retraction
O’Niel 26115935 US | prosp cohort (2009-nr) | various, including Sheehy, Armstrong, T tube, Activent | 3 (2.8) [0.08 – 17’ | 42.4 | 60[38] | 1 year post TT extrusion | 634[544] | 24.00% | nr
Paradise 11309632 US | prosp rct (1991–1995) | Armstrong [TT early treatment; underwent TT insertion at initiaition of symptoms] | 5.00 | 52.6 | 0 [100] | ~2 years | 121 [242] | [40.08%] | segmental atrophy
Pereira 16446953 Brazil | prosp cohort (2001–2002) | Short-term ventilation tubes, made of silicone, measuring 1.2 × 2.6 mm, type Donaldson | 2.89 (1.54) [0.92, 9.33] | 60 | 69.3 [30.7] | 38 months | 75 [150] | 39.73% | nr
Powell 25598389 UK | prosp cohort (2004–2005) | nr | 4.60 | nr | nr | 9 weeks to 10 years | 89 | 12.00% | tympanic membrane retraction pocket
Praveen 15992470 UK | prosp cohort (1998–2003) | Shah ventilation tubes | 5.00 [1.60, 14.50] | 64 | nr | nr | 606 [1174] | [4.43%] | attic reaction postoperatively
Saki 24303379 Iran | prosp cohort (2009–2011) | nr | [0.83, 6.00] | 55.8 | 0 [100] | 12 to 18 months | 208 | 27.88% | tympanic membrane atrophy
Smillie 25171763 Scotland | nrcs (2002–2012) | [no cleft lip palate; underwent VT insertion] | med 3.50 [0.60, 10.40] | 55 | nr | nr | 60 | 2.33% | retracted tympanic membrane; attic retraction
Tos 3814387 Denmark | prosp cohort (1970–1975) | nr | nr | nr | nr | nr | 278 [527] | [14.36%] | atrophy
Tos 985199 Denmark | prosp cohort | nr | nr | 14 | nr | 1 to 8 years | 109 | 5.50% | Adhesive otitis with retracted, immobile drum, an entirely or partially atelectatic middle ear, and poor tubal function
Valtonen 12150521 Finland | prosp cohort (1983–1984) | Shah vent Teflon tube, inner diameter 1.1 mm | 0.84 [0.42, 1.33] | 58.4 | 34.2 [65.8] | 5 years | 281 [281] | 16.73% | retraction of pars flaccida (20); retraction of pars tensa (27)
Valtonen 16094135 Finland | prosp cohort (1983–1993) | Shah vent Teflon tube (Xomed) | nr | 51.4 | 0 [100] | 5 to 7.2 years | 72 [124] | 12.50% | pars tensa retraction of tympanic membrane
Velepic 21397957 Croatia | prosp rct (2004–2009) | nr | 5.44 [2.00, 12.00] | nr | 0 [100] | nr | [161] | [3.11%] | Severe Attic retractions

Table H11 Cholesteotoma

Author PMID Country | Design (recruitment period) | Tube Type [arm desc.] | Age (SD) [min, max] | % male | %rAOM [%COME] | Followup | N [ears] | % Cholesteotoma | def_cholesteotoma
Barfoed 7190819 Denmark | prosp cohort (nr) | nr | nr | 57 | 0[100] | 4.5 to 7.5 years | 90[173] | 0% | nr
Birck 1267356 US | prosp cohort (1972–1974) | nr | nr | 59.2 | nr | 6+ months | 736 [2327] | [0.00%] | nr
Bonding 4215997 US | cohort (1967–1969) | nr | [=<3.00, 4.00] | 66.7 | 0 [100] | 16 to 48 months | 108 [175] | 1.85% | suppurative otitis media with cholesteatoma
Djurhuus 25724629 Denmark | retro cohort (1997–2011) | various [data from National Registers | nr | nr | nr | nr | 217206 | 0.17% | surgically treated
Eliachar 6613541 Israel | prosp cohort (1975–1981) | Goode long-term T-shaped silicone design tubes | 8.33 [4.50, 16.00] | nr | nr | 8 to 72 months | 122 [203] | [1.48%] | developed cholesteatoma in their pre-existing retractions pockets
Golz 10406312 Israel | retro cohort (1978–1997) | “homemade” polyethylene tubes in 5143 ears, Goode T-tubes in 432 ears | 4.80 (2.60) [1.20, 14.00] | 54.4 | 11.4 (ears) [88.6 (ears)] | 1 to 20 years | 2829 [5575] | 2.19% | nr
Gundersen 1267702 Norway | prosp cohort | polyethylene ventilating tube | 7.50 [1.00, 14.00] | nr | 0 [100] | 2 to 11 years | 100 [196] | [5.61%] | cholesteatoma
Heaton 8877228 UK | prosp cohort (1986–1988) | nr | 5.00 [1.00, 12.00] | 60.6 | 0 [100] | nr | 127 | 0.79% | nr
Hörmann 1816937 Germany | prosp nrcs | [cleft palate - University of Hamburg] | 7.43 [5.00, 10.00] | nr | nr | 8 years | 126 [252] | 0.00% | nr
Kinnari 20122337 Finland | prosp rct (2001–2002) | Xomed Soileau Tytan | 4.1[0.5, 15] | 61 | 36[64] | until extrusion or removal | 170[298] | 0.00%
Kokko 1267359 Finland | cohort (1965–1971) | nr | nr | nr | nr | 3.167 years (average) | [290] | [0.69%] | attic cholesteatoma
Luo 25465449 China | prosp nrcs (2011–2012) | [tympanostomy tube insertion] | 4.80 (1.00) [2.00, 8.00] | 50.9 | nr | 2 years | 55 | 10.91% | cholesteatoma in the attic
MacKinnon 4105168 UK | prosp cohort (1965–1971) | nr | =<16.00 | nr | nr | nr | 95 [165] | 6.32% [4.85%] | cholesteatoma after previous exudative otitis media
Muenker 6778334 Germany | prosp cohort (1966–1978) | nr | nr | nr | nr | nr | 631 [1060] | 1.58% | preexisting cholesteatoma was revealed behind an intact tympanic membrane on 3 occasions
O’Niel 26115935 US | prosp cohort (2009-nr) | various, including Sheehy, Armstrong, T tube, Activent | 3 (2.8) [0.08 – 17’ | 42.4 | 60[38] | 1 year post TT extrusion | 634[544] | 0.56% | nr
Paradise 2181158 US | prosp rct/nrcs (1971–1985) | [TT & Adenoidectomy] | nr | 67 | nr | nr | 97 | 0.80% | nr
Pereira 16446953 Brazil | prosp cohort (2001–2002) | Short-term ventilation tubes, made of silicone, measuring 1.2 × 2.6 mm, type Donaldson | 2.89 (1.54) [0.92, 9.33] | 60 | 69.3 [30.7] | 38 months | 75 [150] | [0.00%] | nr
Powell 25598389 UK | prosp cohort (2004–2005) | nr | 4.60 | nr | nr | 9 weeks to 10 years | 89 | 1.33% | otolaryngology-clinic-diagnosed cholesteatoma
Rothera 4040147 UK | prosp cohort (1980–1982) | Xomed silicone Goode T-Tubes (1.1 mm. internal diameter, 12 mm. length) | nr | nr | 0 [100] | 30 months | 73 [131] | 0.00% | nr
Smillie 25171763 Scotland | nrcs (2002–2012) | [no cleft lip palate; underwent VT insertion] | med 3.50 [0.60, 10.40] | 55 | nr | nr | 60 | 3.33% | posterior pars tensa cholesteatoma
Spilsbury 23737350 Austalia | retro cohort (1980–2009) | nr | nr | 59.7 | nr | 11.9 years | 56949 | 1.04% | nr
Tos 3814387 Denmark | prosp cohort (1970–1975) | nr | nr | nr | nr | nr | 278 [527] | [0.28%] | attic cholesteatoma
Tos 7192477 Denmark | cohort | Armstrong tube | nr | nr | 0 [100] | 6 months | [527] | 0.20% | deep retraction pocket, the bottom of which could not be seen
Tos 985199 Denmark | prosp cohort | nr | nr | 14 | nr | 1 to 8 years | 109 | 1.83% | cholesteatoma in the attic

Table H12 Hearing loss

Author PMID Country | Design (recruitment period) | Tube Type [arm desc.] | Age (SD) [min, max] | % male | %rAOM [%COME] | Followup | N [ears] | % Hearing Loss | Definition
Brown 8231117 US | cohort | Goode T-tubes | nr | nr | nr | 6 months | 168 [328] | 1.19% | conductive hearing loss
Costa 3472336 Brazil | prosp cohort | nr | nr | nr | 0 [100] | nr | 79 | 1.27% | unilateral sensorineural hearing loss
Daly 12759263 US | prosp cohort (1987–1990) | nr | [0.50, 8.00] | 61 | nr | 3 to 8 years | 138 [275] | [91.27%] | hearing loss
Daly 9738746 US | cross-sectional (1985–1990) | [children treated with TT] | 17.70 (3.50) [13.00, 28.00] | 61 | 0 [100] | nr | 108 | 10.00% | nr
Gundersen 1267702 Norway | prosp cohort | polyethylene ventilating tube | 7.50 [1.00, 14.00] | nr | 0 [100] | 2 to 11 years | 100 [196] | [20.92%] | hearing was not normal, varying from a pure-tone average (PTA) of 25 to 60 dB hearing level (PTA was measured as the mean hearing loss for the frequencies 500, 1,000 and 2,000 hertz.)
Isaacson 18722211 US | prosp cohort (1997–2007) | Armstrong beveled grommet tube | [0.11, 21.00] | nr | nr | nr | [10000] | 0.02% | profound hearing loss, both were found to have Mondini malformations by CT
Mackenzie 6541254 UK | prosp cohort (1978–1980) | Pappas 1974, Shah 1971 (Exmoor 142, Shepard 137, Bobbin 132, Arrow 58, Shah 131, Armstrong 138, Colar Button 141, Paparella 60) | 10.80 [0.75, 77.00] | 58.3 | 0 [100] | 2.25 years | 588 [939] | 28.38% | by audiometric assessment at 3 month
Owen 8436453 US | prosp cohort | Armstrong bevelled tube | 2.08 [0.42, 4.00] | nr | nr | 6 months | 52 [98] | [7.94%] | moderate hearing loss (27.5–50 dB)
Spielmann 18047760 UK | prosp cohort (2003–2004) | nr [second cohort] | 5.30 [0.83, 9.00] | 61.4 | 18.8 [81.2] | 3 months | 84 [195] | 35.62% | a mean hearing threshold greater than 20 dB
Tuli 23119801 India | cohort | nr | nr | 66.7 | 0 [100] | nr | 100 | 8.00% | worsening of hearing