# Appendix G Patient-Centered and Quality of Life Outcomes

Table G1 Patient-centered and quality of life outcomes

Study author, years | PMIDs | Age | Interventions | No. analyzed | Outcome type | Outcome | Favors | If significant, net difference or OR (95%CI) | P between groups NS = not significant at alpha = 0.05
Paradise, 2001, 2003, 2004, 2005, 2007 | 11309632, 16093466, 12897272, 17229952, 15231974, 12690269 | 3 years | early treatment | 206 | cognitive | McCarthy General Cognitive index | delayed | | NS
| | | delayed treatment | 196
| | 4 years | early treatment | 202–204 | | | delayed | | NS
| | | delayed treatment | 193
| | 3 years | early treatment | 206 | verbal | McCarthy Verbal Subscale | delayed | | NS
| | | delayed treatment | 196
| | 4 years | early treatment | 202–204 | | | delayed | | NS
| | | delayed treatment | 193
| | 3 years | early treatment | 206 | cognitive | McCarthy Perceptual Performance Subscale | delayed | | NS
| | | delayed treatment | 196
| | 4 years | early treatment | 202–204 | | | delayed | | NS
| | | delayed treatment | 193
| | 3 years | early treatment | 206 | cognitive | McCarthy Quantitative Subscale | delayed | | NS
| | | delayed treatment | 196
| | 4 years | early treatment | 202–204 | | | delayed | | NS
| | | delayed treatment | 193
| | 3 years | early treatment | 206 | verbal | Peabody Picture Vocabulary Test–Revised | neither | | NS
| | | delayed treatment | 196
| | 4 years | early treatment | 202–204 | | | delayed | | NS
| | | delayed treatment | 193
| | 6 years | early treatment | 201 | | | neither | | NS
| | | delayed treatment | 194
| | | randomization consent withheld | 101
| | | not eligible for randomization | 233
| | 3 years | early treatment | 206 | verbal | Number of Different Words | delayed | | NS
| | | delayed treatment | 196
| | 4 years | early treatment | 202–204 | | | delayed | | NS
| | | delayed treatment | 193
| | 6 years | early treatment | 201 | | | early | | NS
| | | delayed treatment | 194
| | | randomization consent withheld | 101
| | | not eligible for randomization | 233
| | 3 years | early treatment | 206 | verbal | Mean Length of Utterance in Morphemes | delayed | | NS
| | | delayed treatment | 196
| | 4 years | early treatment | 202–204 | | | neither | | NS
| | | delayed treatment | 193
| | 6 years | early treatment | 201 | | | early | | NS
| | | delayed treatment | 194
| | | randomization consent withheld | 101
| | | not eligible for randomization | 233
| | 3 years | early treatment | 206 | verbal | Percentage of Consonants Correct–Revised | delayed | | NS
| | | delayed treatment | 196
| | 4 years | early treatment | 202–204 | | | delayed | | NS
| | | delayed treatment | 193
| | 6 years | early treatment | 201 | | | neither | | NS
| | | delayed treatment | 194
| | | randomization consent withheld | 101
| | | not eligible for randomization | 233
| | 4 years | early treatment | 202–204 | verbal | Nonword repetition test | delayed | −3.4 (−6.2, −0.7) | <0.05
| | | delayed treatment | 193
| | 6 years | early treatment | 201 | | | delayed | −2 (−4.1, 0.1) | <0.05
| | | delayed treatment | 194
| | | randomization consent withheld | 101
| | | not eligible for randomization | 233
| | 3 years | early treatment | 206 | QOL | Parenting Stress Index - parental distress subscale | delayed | | NS
| | | delayed treatment | 196
| | 4 years | early treatment | 202–204 | | | early | | NS
| | | delayed treatment | 193
| | 6 years | early treatment | 201 | | | delayed | | NS
| | | delayed treatment | 194
| | | randomization consent withheld | 101
| | | not eligible for randomization | 233
| | 3 years | early treatment | 206 | QOL | Parenting Stress Index - parent-child dysfunction subscale | neither | | NS
| | | delayed treatment | 196
| | 4 years | early treatment | 202–204 | | | early | | NS
| | | delayed treatment | 193
| | 6 years | early treatment | 201 | | | neither | | NS
| | | delayed treatment | 194
| | | randomization consent withheld | 101
| | | not eligible for randomization | 233
| | 3 years | early treatment | 206 | QOL | Parenting Stress Index - difficult child subscale | delayed | | NS
| | | delayed treatment | 196
| | 4 years | early treatment | 202–204 | | | delayed | | NS
| | | delayed treatment | 193
| | 6 years | early treatment | 201 | | | neither | | NS
| | | delayed treatment | 194
| | | randomization consent withheld | 101
| | | not eligible for randomization | 233
| | 3 years | early treatment | 206 | QOL | Parenting Stress Index - total stress | delayed | | NS
| | | delayed treatment | 196
| | 4 years | early treatment | 202–204 | | | early | | NS
| | | delayed treatment | 193
| | 6 years | early treatment | 201 | | | neither | | NS
| | | delayed treatment | 194
| | | randomization consent withheld | 101
| | | not eligible for randomization | 233
| | 3 years | early treatment | 206 | Behavior | Child Behavior Checklist - anxious/depressed scale | neither | | NS
| | | delayed treatment | 196
| | 4 years | early treatment | 202–204 | | | early | | NS
| | | delayed treatment | 193
| | 6 years | early treatment | 201 | | | neither | | NS
| | | delayed treatment | 194
| | | randomization consent withheld | 101
| | | not eligible for randomization | 233
| | 3 years | early treatment | 206 | Behavior | Child Behavior Checklist - withdrawn scale | early | | NS
| | | delayed treatment | 196
| | 4 years | early treatment | 202–204 | | | early | | NS
| | | delayed treatment | 193
| | 6 years | early treatment | 201 | | | early | | NS
| | | delayed treatment | 194
| | | randomization consent withheld | 101
| | | not eligible for randomization | 233
| | 3 years | early treatment | 206 | Behavior | Child Behavior Checklist - sleep problems scale | neither | | NS
| | | delayed treatment | 196
| | 3 years | early treatment | 206 | Behavior | Child Behavior Checklist - somatic problems scale | early | | NS
| | | delayed treatment | 196
| | 4 years | early treatment | 202–204 | | | early | | NS
| | | delayed treatment | 193
| | 6 years | early treatment | 201 | | | neither | | NS
| | | delayed treatment | 194
| | | randomization consent withheld | 101
| | | not eligible for randomization | 233
| | 3 years | early treatment | 206 | Behavior | Child Behavior Checklist - aggression scale | early | | NS
| | | delayed treatment | 196
| | 4 years | early treatment | 202–204 | | | early | | NS
| | | delayed treatment | 193
| | 6 years | early treatment | 201 | | | early | | NS
| | | delayed treatment | 194
| | | randomization consent withheld | 101
| | | not eligible for randomization | 233
| | 3 years | early treatment | 206 | Behavior | Child Behavior Checklist - delinquent/destructive scale | early | | NS
| | | delayed treatment | 196
| | 4 years | early treatment | 202–204 | | | early | | NS
| | | delayed treatment | 193
| | 6 years | early treatment | 201 | | | early | | NS
| | | delayed treatment | 194
| | | randomization consent withheld | 101
| | | not eligible for randomization | 233
| | 3 years | early treatment | 206 | Behavior | Child Behavior Checklist - total problems | early | | NS
| | | delayed treatment | 196
| | 4 years | early treatment | 202–204 | | | early | | NS
| | | delayed treatment | 193
| | 9–11 years | early treatment | 194 | | | early | 2 (0.1, 4.8) | <0.05
| | | delayed treatment | 196
| | | randomization consent withheld | 127
| | | not eligible for randomization | 223
| | 4 years | early treatment | 202–204 | Behavior | Child Behavior Checklist - social problems | early | | NS
| | | delayed treatment | 193
| | 6 years | early treatment | 201 | | | neither | | NS
| | | delayed treatment | 194
| | | randomization consent withheld | 101
| | | not eligible for randomization | 233
| | 4 years | early treatment | 202–204 | Behavior | Child Behavior Checklist - thought problems | early | | NS
| | | delayed treatment | 193
| | 6 years | early treatment | 201 | | | neither | | NS
| | | delayed treatment | 194
| | | randomization consent withheld | 101
| | | not eligible for randomization | 233
| | 4 years | early treatment | 202–204 | Behavior | Child Behavior Checklist - attention problems | early | | NS
| | | delayed treatment | 193
| | 6 years | early treatment | 201 | | | neither | | NS
| | | delayed treatment | 194
| | | randomization consent withheld | 101
| | | not eligible for randomization | 233
| | 6 years | early treatment | 201 | verbal | Screening Test for Auditory Processing Disorders | delayed | | NS
| | | delayed treatment | 194
| | | randomization consent withheld | 101
| | | not eligible for randomization | 233
| | 6 years | early treatment | 201 | cognitive | Wechsler Intelligence Scale for Children - full scale IQ | neither | | NS
| | | delayed treatment | 194
| | | randomization consent withheld | 101
| | | not eligible for randomization | 233
| | 9–11 years | early treatment | 195 | | | not eligible | | NS
| | | delayed treatment | 196
| | | randomization consent withheld | 127
| | | not eligible for randomization | 223
| | 6 years | early treatment | 201 | cognitive | Wechsler Intelligence Scale for Children - Verbal IQ | neither | | NS
| | | delayed treatment | 194
| | | randomization consent withheld | 101
| | | not eligible for randomization | 233
| | 6 years | early treatment | 201 | cognitive | Wechsler Intelligence Scale for Children - Performance IQ | delayed | | NS
| | | delayed treatment | 194
| | | randomization consent withheld | 101
| | | not eligible for randomization | 233
| | 9–11 years | early treatment | 195 | cognitive | Woodcock Reading Mastery Tests, revised, normative updated version - word identification subtest | delayed/not eligible | | NS
| | | delayed treatment | 196
| | | randomization consent withheld | 127
| | | not eligible for randomization | 223
| | 9–11 years | early treatment | 195 | cognitive | Woodcock Reading Mastery Tests, revised, normative updated version - word attack subtest | delayed/not eligible | | NS
| | | delayed treatment | 196
| | | randomization consent withheld | 127
| | | not eligible for randomization | 223
| | 9–11 years | early treatment | 195 | cognitive | Woodcock Reading Mastery Tests, revised, normative updated version - passage comprehension subtest | delayed/not eligible | | NS
| | | delayed treatment | 196
| | | randomization consent withheld | 127
| | | not eligible for randomization | 223
| | grade 3 (9) | early treatment | 37 | verbal | Oral Reading Fluency Test | delayed | | NS
| | | delayed treatment | 37
| | | randomization consent withheld | 28
| | | not eligible for randomization | 2
| | grade 4 (9–10) | early treatment | 87 | verbal | Oral Reading Fluency Test | not eligible | 20 (compared to rct both arms the same); −17 (compared to randomization consent withheld) | <0.05
| | | delayed treatment | 97
| | | randomization consent withheld | 63
| | | not eligible for randomization | 81
| | grade 5 (10–11) | early treatment | 54 | verbal | Oral Reading Fluency Test | delayed/not eligible | | NS
| | | delayed treatment | 51
| | | randomization consent withheld | 29
| | | not eligible for randomization | 115
| | grade 6 (11) | early treatment | 12 | verbal | Oral Reading Fluency Test | early/not eligible | | NS
| | | delayed treatment | 9
| | | randomization consent withheld | 5
| | | not eligible for randomization | 24
| | 9–11 years | early treatment | 194 | cognitive | Woodcock-Johnson III Tests of Achievement, Standard Battery -- spelling subtest | not eligible | 5 (compared to early/randomization withheld); −4 (compared to late) | <0.05
| | | delayed treatment | 196
| | | randomization consent withheld | 127
| | | not eligible for randomization | 223
| | 9–11 years | early treatment | 192 | cognitive | Woodcock-Johnson III Tests of Achievement, Standard Battery -- writing samples subtest | delayed/not eligible | | NS
| | | delayed treatment | 195
| | | randomization consent withheld | 125
| | | not eligible for randomization | 223
| | 9–11 years | early treatment | 194 | cognitive | Woodcock-Johnson III Tests of Achievement, Standard Battery -- calculation subtest | not eligible | | NS
| | | delayed treatment | 195
| | | randomization consent withheld | 127
| | | not eligible for randomization | 223
| | 9–11 years | early treatment | 195 | verbal | Comprehensive Test of Phonologial Processing - Elision subtest | delayed/not eligible | | NS
| | | delayed treatment | 196
| | | randomization consent withheld | 127
| | | not eligible for randomization | 223
| | 9–11 years | early treatment | 195 | verbal | Comprehensive Test of Phonologial Processing - Rapid Letter Naming subtest | delayed/not eligible | | NS
| | | delayed treatment | 196
| | | randomization consent withheld | 127
| | | not eligible for randomization | 223
| | 9–11 years | early treatment | 195 | verbal | Children’s Version of the Hearing in Noise Test - competing noise from the front | early | | NS
| | | delayed treatment | 196
| | | randomization consent withheld | 127
| | | not eligible for randomization | 223
| | 9–11 years | early treatment | 195 | verbal | Children’s Version of the Hearing in Noise Test - competing noise from the right | randomization consent witheld | 1.4 (compared to not eligible) | <0.05
| | | delayed treatment | 196
| | | randomization consent withheld | 127
| | | not eligible for randomization | 223
| | 9–11 years | early treatment | 195 | verbal | Children’s Version of the Hearing in Noise Test - competing noise from the left | early | 0.8 (compared to not eligible) | <0.05
| | | delayed treatment | 196
| | | randomization consent withheld | 127
| | | not eligible for randomization | 223
| | 9–11 years | early treatment | 194 | Behavior | Disruptive Behavior Disorders Rating Scale - inattention factor | early | | NS
| | | delayed treatment | 196
| | | randomization consent withheld | 126
| | | not eligible for randomization | 223
| | 9–11 years | early treatment | 194 | Behavior | Disruptive Behavior Disorders Rating Scale - impulsitivity and overactivity factor | early | 0.20 (compared to not eligible) | <0.05
| | | delayed treatment | 196
| | | randomization consent withheld | 126
| | | not eligible for randomization | 223
| | 9–11 years | early treatment | 194 | Behavior | Disruptive Behavior Disorders Rating Scale - oppositional defiant factor | early/randomization withheld | | NS
| | | delayed treatment | 196
| | | randomization consent withheld | 126
| | | not eligible for randomization | 223
| | 9–11 years | early treatment | 194 | cognitive | Impairment Rating Scales - Overall functioning | early | 0.18 (compared to not eligible) | <0.05
| | | delayed treatment | 196
| | | randomization consent withheld | 127
| | | not eligible for randomization | 223
| | 9–11 years | early treatment | 194 | Behavior | Social Skills Rating System | delayed/not eligible | | NS
| | | delayed treatment | 194
| | | randomization consent withheld | 126
| | | not eligible for randomization | 223
| | 9–11 years | early treatment | 195 | cognitive | Visual Continuous Performance Test - Inattention | early/randomization withheld | | NS
| | | delayed treatment | 196
| | | randomization consent withheld | 127
| | | not eligible for randomization | 223
| | 9–11 years | early treatment | 195 | cognitive | Visual Continuous Performance Test - Impulsivity | early/randomization withheld | | NS
| | | delayed treatment | 196
| | | randomization consent withheld | 127
| | | not eligible for randomization | 223
| | 9–11 years | early treatment | 155 | verbal | Auditory Continuous Performance Test - Inattention | delayed/randomization withheld | | NS
| | | delayed treatment | 153
| | | randomization consent withheld | 100
| | | not eligible for randomization | 128
| | 9–11 years | early treatment | 155 | verbal | Auditory Continuous Performance Test - Inattention | delayed | | NS
| | | delayed treatment | 153
| | | randomization consent withheld | 100
| | | not eligible for randomization | 128
Rach 1991 | 2070526 | ND | TT | 22 | verbal | verbal comprehension score | TT | | NS
Rach 1991 | 2070526 | ND | control | 21 | verbal | verbal comprehension score
Rach 1991 | 2070526 | ND | TT | 21 | verbal | verbal expression score | TT | | NS
Rach 1991 | 2070526 | ND | control | 20 | verbal | verbal expression score
Schilder 1997 | 9372253 | 2–4 years | TT | 13 | verbal | language measures: word forms production | TT | 26.4 (SD 0.92) | P=0.03
| | | control | 14
| | 2–4 years | TT | 13 | verbal | language measures: concealed meaning | TT | | NS
| | | control | 14
| | 2–4 years | TT | 13 | verbal | language measures: phonemic segmentation | TT | | NS
| | | control | 14
| | 2–4 years | TT | 13 | verbal | language measures: sound blending | control | | NS
| | | control | 14
| | 2–4 years | TT | 13 | verbal | language measures: auditory discrimination | TT | 0.08 (SD 0.03) | P=0.03
| | | control | 14
Rovers 2000 | 10969126 | 0.5 years | TT | 93 | verbal | Reynell test (comprehensive language development) | watchful waiting | | NS
| | | watchful waiting | 94
| | 1 year | TT | 93 | verbal | Reynell test (comprehensive language development) | TT | | NS
| | | watchful waiting | 94
| | 0.5 years | TT | 93 | verbal | Schlichting test (expressive language development) | watchful waiting | | NS
| | | watchful waiting | 94
| | 1 year | TT | 93 | verbal | Schlichting test (expressive language development) | watchful waiting | | NS
| | | watchful waiting | 94
Peters 1994 | 8195687 | 93 months | TT | 37 | verbal | Grapheme (%) | TT | | NS
| | | Control | 151
| | 93 months | TT | 37 | cognitive | Spelling: Words (%) | TT | | NS
| | | Control | 151
| | 93 months | TT | 37 | cognitive | Spelling: Pseudowords (%) | TT | | NS
| | | Control | 151
| | 93 months | TT | 37 | cognitive | One-Minute (# correct) | TT | | NS
| | | Control | 151
| | 93 months | TT | 37 | cognitive | Sentence Verification: Correct sentences (msec) | TT | | NS
| | | Control | 151
| | 93 months | TT | 37 | cognitive | Sentence Verification: Incorrect sentences (msec) | TT | | NS
| | | Control | 151
| | 93 months | TT | 37 | cognitive | Sentence Verification: Correct sentences (%) | TT | | NS
| | | Control | 151
| | 93 months | TT | 37 | cognitive | Sentence Verification: Incorrect sentences (%) | TT | | NS
| | | Control | 151
| | 93 months | TT | 37 | cognitive | Teachers’ Ratings: Writing 1 | TT | | <0.001
| | | Control | 151
| | 93 months | TT | 37 | cognitive | Teachers’ Ratings: Writing 2 | Control | | NS
| | | Control | 151
| | 93 months | TT | 37 | cognitive | Teachers’ Ratings: Reading 3 | TT | | NS
| | | Control | 151
| | 93 months | TT | 37 | cognitive | Teachers’ Ratings: Reading 4 | neither | | NS
| | | Control | 151
| | 93 months | TT | 37 | cognitive | Teachers’ Ratings: Reading 5 | Control | | NS
| | | Control | 151
| | 93 months | TT | 37 | cognitive | Teachers’ Ratings: Arithmetic 6 | Control | | NS
| | | Control | 151
| | 93 months | TT | 37 | cognitive | Teachers’ Ratings: Arithmetic 7 | Control | | NS
| | | Control | 151
| | 93 months | TT | 37 | cognitive | Teachers’ Ratings: Arithmetic 8 | neither | | NS
| | | Control | 151
| | 93 months | TT | 37 | verbal | Word Recognition: Words (msec) | TT | | NS
| | | Control | 151
| | 93 months | TT | 37 | verbal | Word Recognition: Pseudowords (msec) | TT | | NS
| | | Control | 151
| | 93 months | TT | 37 | verbal | Word Recognition: Words (%) | TT | | NS
| | | Control | 151
| | 93 months | TT | 37 | verbal | Word Recognition: Pseudowords (%) | Control | | NS
| | | Control | 151
Grievink 1993 | 8246466 | 93 months | TT | 132 | verbal | Word Forms Production | neither | | NS
| | | Control | 51
| | 93 months | TT | 132 | cognitive | Concealed Meaning | Control | | NS
| | | Control | 51
| | 93 months | TT | 132 | verbal | Phonemic Segmentation: Words | Control | | NS
| | | Control | 51
| | 93 months | TT | 132 | verbal | Phonemic Segmentation: Pseudo | Control | | NS
| | | Control | 51
| | 93 months | TT | 132 | verbal | Sound Blending: Words | TT | | NS
| | | Control | 51
| | 93 months | TT | 132 | verbal | Sound Blending: Pseudo | Control | | NS
| | | Control | 51
| | 93 months | TT | 132 | verbal | Auditory Discrimination of Unequal Pairs: Words | Control | | NS
| | | Control | 51
| | 93 months | TT | 132 | verbal | Auditory Discrimination of Unequal Pairs: Pseudo | Control | | NS
| | | Control | 51
| | 93 months | TT | 132 | verbal | Auditory Discrimination of Equal Pairs: Words | TT | | NS
| | | Control | 51
| | 93 months | TT | 132 | verbal | Auditory Discrimination of Equal Pairs: Pseudo | TT | | NS
| | | Control | 51
Hall 2009 | 19260880 | 4.5 years | Early surgery | 76 | cognitive | School entry: Language | Early surgery | OR: 3.45 (1.42, 8.39) | 0.006
| | | Watchful waiting | 60
| | 4.5 years | Early surgery | 76 | cognitive | School entry: Reading | Watchful waiting | | NS (0.510)
| | | Watchful waiting | 60
| | 4.5 years | Early surgery | 76 | cognitive | School entry: Writing | Early surgery | OR: 3.74 (1.51, 9.27) | 0.004
| | | Watchful waiting | 60
| | 4.5 years | Early surgery | 76 | cognitive | School entry: Mathematics | Early surgery | | NS (0.197)
| | | Watchful waiting | 60
| | 7–8 years | Early surgery | 27 | Behavior | Behaviour - teacher report: Prosocial | Early surgery | | NS (0.877)
| | | Watchful waiting | 24
| | 7–8 years | Early surgery | 27 | Behavior | Behaviour - teacher report: Hyperactivity | Early surgery | | NS (0.363)
| | | Watchful waiting | 24
| | 7–8 years | Early surgery | 27 | Behavior | Behaviour - teacher report: Emotional problems | Early surgery | OR: 4.11 (1.15, 14.64) | 0.029
| | | Watchful waiting | 24
| | 7–8 years | Early surgery | 27 | Behavior | Behaviour - teacher report: Conduct problems | Watchful waiting | | NS (0.803)
| | | Watchful waiting | 24
| | 7–8 years | Early surgery | 27 | Behavior | Behaviour - teacher report: Peer problems | Early surgery | | NS (0.816)
| | | Watchful waiting | 24
| | 7–8 years | Early surgery | 27 | Behavior | Behaviour - teacher report: Total score | Early surgery | | NS (0.237)
| | | Watchful waiting | 24
| | 7–8 years | Early surgery | 35 | verbal | Speech/language: Comprehension | Early surgery | | NS (0.366)
| | | Watchful waiting | 33
| | 7–8 years | Early surgery | 34 | verbal | Speech/language: Oral expression | Early surgery | | NS (0.143)
| | | Watchful waiting | 32
| | 7–8 years | Early surgery | 35 | verbal | Speech/language: Non-word: 3 syllable | Early surgery | | NS (0.773)
| | | Watchful waiting | 32
| | 7–8 years | Early surgery | 35 | verbal | Speech/language: Non-word: 4 syllable | Early surgery | | NS (0.656)
| | | Watchful waiting | 32
| | 7–8 years | Early surgery | 35 | verbal | Speech/language: Non-word: 5 syllable | Early surgery | | NS (0.101)
| | | Watchful waiting | 32
| | 7–8 years | Early surgery | 35 | verbal | Speech/language: Non-word: total | Early surgery | | NS (0.288)
| | | Watchful waiting | 32
| | 7–8 years | Early surgery | 36 | cognitive | IQ: Verbal IQ | Early surgery | | NS (0.265)
| | | Watchful waiting | 30
| | 7–8 years | Early surgery | 32 | cognitive | IQ: Performance IQ | Early surgery | | NS (0.145)
| | | Watchful waiting | 30
| | 7–8 years | Early surgery | 29 | cognitive | IQ: Total IQ | Early surgery | | NS (0.100)
| | | Watchful waiting | 29
| | 7–8 years | Early surgery | 81 | cognitive | SATS KS1: Reading overall | Early surgery | | NS (0.258)
| | | Watchful waiting | 64
| | 7–8 years | Early surgery | 81 | cognitive | SATS KS1: Writing | Early surgery | | NS (0.192)
| | | Watchful waiting | 64
| | 7–8 years | Early surgery | 81 | cognitive | SATS KS1: Mathematics | Early surgery | | NS (0.079)
| | | Watchful waiting | 64
Maw 1999 | 10459904 | 18 months | TT (Tympanostomy tubes within 6 weeks) | 75 | verbal | Verbal comprehension: standardized score | TT | | NS (0.14)
| | | Watchful waiting (for 9 months then tubes if needed) | 67
| | 18 months | TT (Tympanostomy tubes within 6 weeks) | 75 | verbal | Expressive language: standardized score | TT | | NS (0.059)
| | | Watchful waiting (for 9 months then tubes if needed) | 67
| | 18 months | TT (Tympanostomy tubes within 6 weeks) | 75 | verbal | Verbal comprehension: chronological age/equivalent age | TT | | NS (0.36)
| | | Watchful waiting (for 9 months then tubes if needed) | 67
| | 18 months | TT (Tympanostomy tubes within 6 weeks) | 75 | verbal | Expressive language: chronological age/equivalent age | TT | | NS (0.36)
| | | Watchful waiting (for 9 months then tubes if needed) | 67
| | 18 months | TT (Tympanostomy tubes within 6 weeks) | 75 | Behavior | Richman score >= 10 | TT | | NS (0.66)
| | | Watchful waiting (for 9 months then tubes if needed) | 67
| | 18 months | TT (Tympanostomy tubes within 6 weeks) | 75 | Behavior | Richman score | TT | | NS (0.13)
| | | Watchful waiting (for 9 months then tubes if needed) | 67
Vlastos 2011 | 21205368 | 1 year | TT AND adenoidectomy | 22 | QOL | OM-6 | Myringotomy AND adenoidectomy | | NS
| | | Myringotomy AND adenoidectomy | 23