# Appendix F Risk of Bias

Table F1 Risk of bias, RCTs

Study | Random sequence generation | Allocation concealment | Blinding of participants | Blinding of personnel/care providers | Blinding of outcome assessor | Incomplete outcome data | Selective Reporting | Intention-to-treat-analysis | Group similarity at baseline | Co-interventions
Bernard 1991 1861917 | Unclear | Unclear | High | High | Low | Low | Unclear | Low | Low | Unclear
Casselbrant 2009 19819563 | Unclear | Unclear | High | High | Unclear | High | Unclear | Low | Low | Unclear
D’Eredità 2006 16406076 | Unclear | Unclear | High | High | High | Low | High | Low | Unclear | Low
Gates 1987 3683478 | Low | Low | High | High | Low | Low | Low | Low | Low | Unclear
Mandel 1989 2789777 | Unclear | Unclear | High | High | Unclear | Low | Unclear | High | Low | Unclear
Mandel 1992 1565550 | Unclear | Unclear | High | High | High | Low | Unclear | Unclear | Low | Unclear
Maw 1999 10459904 | Unclear | Unclear | High | High | High | High | Low | Low | Low | Unclear
MRC Multicenter Otitis Media Study Group 2003 12680834 | High | High | High | High | Unclear | High | Unclear | High | Unclear | Unclear
MRC Multicentre Otitis Media Study Group 2012 22443163 | High | Unclear | High | High | High | Low | Unclear | Low | Low | Unclear
Nguyen 2004 15126745 | Unclear | Unclear | High | High | High | Low | Unclear | Low | Low | Unclear
Paradise 2001 11309632 | Low | Low | High | High | High | Low | Low | Low | Low | Unclear
Popova 2010 20399511 | Unclear | Unclear | Unclear | Unclear | Unclear | Low | Low | High | Low | Low
Rach 1991 2070526 | High | Unclear | High | High | High | High | Unclear | High | Unclear | High
Rovers 2000 10969126 | Unclear | Unclear | High | High | Unclear | Low | Unclear | Low | Low | Low
Velepic 2011 21397957 | Unclear | Unclear | High | Unclear | Unclear | Low | Low | Low | Low | Low
Vlastos 2011 21205368 | Low | Unclear | High | High | Unclear | High | Low | Low | Low | Low
Casselbrant 1992 1565551 | Unclear | Unclear | High | High | High | High | Low | Low | Low | Low
El-Sayed 1996 | Unclear | Unclear | High | High | High | Low | Unclear | Low | Low | Low
Gonzalez 1986 3537596 | Low | Unclear | High | High | High | Low | Unclear | Low | Low | High
Hammaren-Malmi 2005 15995051 | Unclear | Unclear | High | High | Unclear | High | Low | Low | Low | Low
Hammarén-Malmi 2005 15995051 | Unclear | Unclear | High | High | Unclear | Low | Unclear | Low | Low | Unclear
Kujala 2012 22466327, 24445832 | Low | Low | High | High | High | Low | Low | Low | Low | Unclear
Mattila 2003 12578443 | Unclear | Low | High | High | High | Low | Unclear | Low | Low | High
Goldstein 2005 15689760 | Unclear | Unclear | High | Unclear | Low | Low | Low | Low | Low | Unclear
Parker 1993 8024107 | Low | Unclear | High | Unclear | Unclear | High | Unclear | High | Unclear | Unclear
Dohar 2006 16880248 | Low | Low | High | High | Low | Low | Low | Low | Low | Low
Goldblatt 1998 10190709 | Low | High | High | High | Low | Low | Low | Low | Low | Low
Granath 2008 18565598 | Low | High | High | High | High | Low | Low | Low | Low | Low
Heslop 2010 20979100 | Unclear | Low | Low | Low | Low | Unclear | Low | Low | Low | Low
Roland 2003 14660913 | Unclear | Unclear | Low | Unclear | Unclear | Low | Low | Low | Low | Low
Roland 2004 14702493 | Unclear | Unclear | High | High | Low | High | Low | High | Low | Low
Ruohola 1999 10190921 | Low | Low | Low | Low | Low | Low | Unclear | Low | Low | Low
Ruohola 2003 12728089 | Low | Low | Low | Low | Low | Low | Unclear | Low | Low | Low
Strachan 2000, 10865480 | Low | Low | High | Low | Low | Low | Low | Low | Unclear | Low
van Dongen 2014 24552319 | Low | Low | High | High | Low | Low | Low | Low | Low | Unclear

Table F2 Risk of bias, NRCSs

Study | Is the case definition adequate? | Representativeness of the cases | Selection of Controls | Definition of Controls | Ascertainment of Exposure | Same method of ascertainment for cases and controls | Non-Response rate | Allocation concealment | Dropout rate <20 percent | Blinded patient | Blinded outcome assessment | ITT | Appt. statistical analysis | If multicenter, was this accounted for in analysis? | Were potential confounders properly accounted for? | Clear reporting with no discrepancies | Were eligibility criteria clear? | Was selection bias likely? | Were interventions adequately described?
Li 2015 26281253 | Yes | Potential for selection biases or not stated | Hospital controls | No TT, no accumulation of fluid or serous fluid in the middle ear | No description | Yes | Non respondents described | | No | No | No | NA | No | | No | No | Yes | No | Yes
Tian 2015 26103659 | Yes | Potential for selection biases or not stated | Hospital controls | no TT | Surgical records | Yes | Non respondents described | | Not reported | No | No | NA | No | | No | Yes | Yes | No | No
Coyte 2001 11309633 | Yes | Potential for selection biases or not stated | Hospital controls | TT only | Written self report or medical record only | Yes | Same rate for both groups | Na | Yes | No | No | No | Yes | No | Yes | Yes | Yes | No | Yes
De Beer 2004 15224825 | Yes | Birth cohort | OM score | OM+ highest tercile, not treated with TT | Prospective cohort | Yes | Low | | | | | | Yes | No | Yes | Yes | Yes | No | Yes
Forquer 1982 6184891 | Unsure | Potential for selection biases or not stated | Hospital controls | Medical treatment (underwent medical treatment but not surgery for VT insertion) | Written self report or medical record only | Yes | Same rate for both groups | Na | Yes | No | No | No | No | Na | No | No | Yes | Yes | No
Grievink 1993 8246466 | Yes | Consecutive or obviously representative series of cases^*^ | Community controls^*^ | OME but no TT | Written self report or medical record only | Yes | Rate different and no designation | Na | No | No | No | No | Yes | Na | Yes | Yes | Yes | Yes | Yes
Hu 2015 26429601 | | Potential for selection biases or not stated | Hospital controls | TT only | Medical record review | Yes | | | | | | | Unlcear | | No | Yes | Yes | Yes | Yes
Hubbard 1985 4039792 | Unsure | Potential for selection biases or not stated | No description | No description of source | No description | Yes | Same rate for both groups^*^ | Na | Yes | No | No | Yes | Yes | Yes | Yes | No | No | No | Yes
Kadhim 2007 17279052 | No | Potential for selection biases or not stated | Hospital controls | TT | Written self report or medical record only | Yes | Same rate for both groups | Na | No | No | No | No | Yes | Na | Yes | Yes | No | No | Yes
Kobayashi 2012 22386274 | Yes | Potential for selection biases or not stated | Hospital controls | no TT | No description | unclear | Non respondents described | Na | Yes | No | No | No | Yes | Na | No | Yes | No | Yes | No
Kuşcu-2015-26545930 .pdf | Yes | Potential for selection biases or not stated | Hospital controls | Late TT, never TT insertion | Medical record review | Yes | Unclear | | | | | | No | | No | Yes | Yes | Unclear | Yes
Marshak 1980 6778336 | Yes | Potential for selection biases or not stated | No description | No description of source | No description | Yes | Same rate for both groups^*^ | No | No | No | No | No | Yes | Na | Nd | No | No | No | No
Motta 2006 17465378 | Yes | Consecutive or obviously representative series of cases^*^ | Community controls (Appropriate controls) | No TT, otherwise same surgery | Secure record (eg surgical records)^*^ | Yes | | | | | | | No | No | No | Yes | Yes | No | No
Niclasen 2016 27063746 | No | Parent report. Unclear defiinition of OM | Self report | 4+ incidences of OM without TT | Parental report | Yes | Unclear | | | | | | | | Yes | Yes | No | Unclear | No
Peters 1994 8195687 | Yes | Consecutive or obviously representative series of cases^*^ | Community controls^*^ | OME but no TT | | unclear | | Na | No | No | Nd | No | No | Na | No | No | Yes | Yes | No
Reiter 2009 19929085 | Yes | Consecutive or obviously representative series of cases^*^ | Hospital controls | no TT | Written self report or medical record only (Case notes) | Yes | Same rate for both groups^*^ | Na | Yes | No | Nd | Na | No | Na | No | Yes | Yes | Yes | No
Robson 1992 1431515 | Yes | Potential for selection biases or not stated | Hospital controls | No tubes (Undergone surgery for cleft palate but did not have tubes inserted) | Written self report or medical record only (Case notes) | Yes | Same rate for both groups^*^ | Na | Yes | No | No | Nd | No | Na | No | No | Yes | Yes | Yes
Schilder 1997 9372253 | Yes | Consecutive or obviously representative series of cases^*^ | No description | no TT | | unclear | unknown relative non-response rate | Na | unclear | No | Nd | Yes | No | unclear | Yes | Yes | Yes | no | No
Stenstrom 2005 16330739 | Yes | Potential for selection biases or not stated | Hospital controls | medical treatment (underwent medical treatment but not surgery for VT insertion) | based off an RCT | Yes | Same rate for both groups^*^ | Nd | No | Nd | Yes | No | Yes | Na | Yes | Yes | Yes | Yes | Yes
Wolter 2012 22883987 | No | Potential for selection biases or not stated | Hospital controls | no TT | | Yes | Same rate for both groups^*^ | No | Yes | No | No | Nd | No | Na | No | No | No | Yes | No
Xu 2003 12930655 | No | Potential for selection biases or not stated | Hospital controls | no TT | | no description | Same rate for both groups^*^ | Na | unclear | No | Nd | Yes | No | Na | No | Yes | No | Yes | No
Xu 2003 12930655 | No | Potential for selection biases or not stated | Hospital controls | no TT | No description | no description | Non respondents decribed | Not Applicable | No | No | Unclear | Yes | | | No | Yes | No | Yes | No
Yagi 1977 321716 | Yes | Potential for selection biases or not stated | Hospital controls | no TT (only adenoidectomy) | | unclear | Same rate for both groups^*^ | Na | Yes | No | No | Yes | No | Na | No | Yes | Yes | Yes | Yes
Yousaf 2012 23855103 | Yes | Potential for selection biases or not stated | No description | No TT (medical management) | | unclear | Same rate for both groups^*^ | Na | No | Nd | Nd | No | No | Na | No | Yes | Yes | No | No
Youssef 2013 24265883 | Yes | Potential for selection biases or not stated | Hospital controls | no TT | | unclear | Non respondents described | Na | Yes | No | Nd | Nd | No | Na | No | Yes | Yes | Yes | Yes
Grindler 2014 24627408 | No | Potential for selection biases or not stated | Hospital controls | no TT insertion | Secure record)^*^ | Yes | unknown relative non-response rate | Not Applicable | Not Applicable | No | No | No | Yes | No | Yes | No | Yes | No | Yes
Becker 1987 3586818 | Yes | Potential for selection biases or not stated | parental choice | Parental choice | Written self report or medical record only | Yes | unknown relative non-response rate | Not Applicable | No | No | No | No analysis done. | Not Applicable | Not Applicable | Yes | Yes | Yes | Yes | No
Cohen 1994 8289048 | Yes | Potential for selection biases or not stated | same cohort of tubes | same cohort of tubes, but nonswimmers | Written self report or medical record only | Yes | Same rate for both groups^*^ | Not Applicable | Yes | No | No | No analysis done. | Not Applicable | Not Applicable | Yes | Yes | No | Yes | No
el Silimy 1986 3780019 | Yes | Potential for selection biases or not stated | same surgical cohort | nonswimmers | Written self report or medical record only | Yes | Same rate for both groups^*^ | Not Applicable | Yes | No | No | No analysis done. | Not Applicable | Not Applicable | Yes | Yes | No | Yes | Yes
Francois 1992 1485779 | | Potential for selection biases or not stated | Parental and patient choice -observational only | Children who did not swim | Parental retrospective report | Yes | Unknown relative non-response rate | | | | | | Yes | No | No | Yes | No | Yes | No
Kaufmann 1999 10546304 | Yes | Consecutive or obviously representative series of cases^*^ | same cohort | no water protection | Written self report or medical record only | Yes | Same rate for both groups^*^ | Yes | No | No | Yes | Yes | Not Applicable | Yes | Yes | Yes | No | Yes | Yes
Konradsson 1986 3784716 | Yes | Even-odd randomization | Same surgical cohort | Children not given intructions to avoid swimming | Unclear | Yes | 11% | No | Yes | No | No | Unclear | No | | No | No | Yes | Yes | No
Salata 1996 8607955 | Yes | Consecutive or obviously representative series of cases^*^ | parent selection | recieved differnt prophylaxis | Written self report or medical record only | Yes | unknown relative non-response rate | Not Applicable | No | No | No | Yes | Yes | Yes | Yes | Yes | unclear - high dropout | Yes | Yes
Sharma 1986 3472335 | Yes | Parental choice | Parental choice | Chldren whose parents chose to let them swim | Unclear | Yes | Unclear | | | | | | No | | No | No | Yes | Yes | No
Smelt 1984 6538215 | Yes | unclear | same surgical cohort | nonswimmers | Written self report or medical record only | Yes | unclear | Not Applicable | No | No | Unclear | Not Appiicable | No | No | No | No | No | No | No
Dohar 1999 10326811 | Yes | Consecutive or obviously representative series of cases^*^ | Hospital controls | historical and concurrent with the same dx | Secure record (eg surgical records)^*^ | Yes | Same rate for both groups^*^ | Not Applicable | No | No | No | No | No | No | No | Yes | Yes | Yes | No