# Appendix E Baseline Characteristics

Table E1 Key Question 1 baselines

Study | Arm | Age (y), mean (range) | Age of onset (y) | Average hearing level mean (SD) | No. of siblings mean (SD) | No. of OME episodes mean | Hearing loss mean | Male gender n/N (%) | Poverty/low SES n/N (%) | Cigarette smoke exposure n/N (%) | Daycare n/N (%)
Augustsson 2006 16214225 | TT | | | | | | | 61/61 (100)
Augustsson 2006 16214225 | Control | | | | | | | 173/173 (100)
Bernard 1991 1861918 | Myringotomy+TT | 4.7 | | 30.7 | | 2.9 | | 34/60 (56.7)
Bernard 1991 1861919 | Antibiotic prophylaxis | 5 | | 29.6 | | 3.0 | | 34/65 (52.3)
Casselbrant 2009 19819564 | Myringotomy+TT | [2, 3.9] | | | | | | 19/32 (59.4)
Casselbrant 2009 19819565 | TT AND myringotomy AND adenoidectomy | [2, 3.9] | | | | | | 24/32 (75.0)
Casselbrant 2009 19819566 | Myringotomy AND adenoidectomy | [2, 3.9] | | | | | | 22/34 (64.7)
Chaudhuri 2006 23120310 | Total | [0, 12]
Coyte 2001 11309633 | TT | Median: 2 [IQR 1, 5] | | | | | | 16296/26714 (61)
Coyte 2001 11309634 | TT AND adenoidectomy | Median: 4 [IQR 3, 6] | | | | | | 2475/4125 (60)
De Beer 2004 15224825 | TT | | | | | | | 24/51 (47)
De Beer 2004 15224825 | Control | | | | | | | 63/132 (48)
Gates 1989 2492179 | Myringotomy | | 2.3 | | 0.43 (with otitis media) | | | 65/107 (61) | 52/107 (49)
Gates 1989 2492180 | Myringotomy+ TT | | 2.2 | | 0.48 (with otitis media) | | | 75/129 (58) | 70/129 (54)
Gates 1989 2492181 | Myringotomy AND adenoidectomy | | 2.3 | | 0.46 (with otitis media) | | | 77/130 (59) | 73/130 (56)
Gates 1989 2492182 | TT AND myringotomy AND adenoidectomy | | 2.3 | | 0.49 (with otitis media) | | | 73/125 (58) | 63/125 (50)
Gates 1988 3336263 | Total | [4, 8]
Gates 1988 3336267 | TT AND myringotomy AND adenoidectomy
Gates 1987 3683478 | Myringotomy | 69% 4.0–6.5 | 2.3 | | | | | 65/107 (61) | 52/107 (49)
Gates 1987 3683479 | TT | 69% 4.0–6.5 | 2.2 | | | | | 75/129 (58) | 70/129 (54)
Gates 1987 3683480 | Myringotomy AND adenoidectomy | 73% 4.0–6.5 | 2.3 | | | | | 77/130 (59) | 73/130 (56)
Gates 1987 3683481 | TT AND adenoidectomy | 74% 4.0–6.5 | 2.3 | | | | | 73/125 (58) | 63/125 (50)
Gates 1985 4040338 | TT
Gates 1985 4040339 | Myringotomy
Grievink 1993 8246466 | Control | 7.75 (2) | | | | | | 80/151 (53%)
Grievink 1993 8246466 | TT | −1.9 | | | | | | 23/37 (62.2%)
Hall 2009 19260880 | Total | 3 [1.25, 4.67]
Hall 2009 19260881 | Early TT | | | | | | | 49/88 (56)
Hall 2009 19260882 | Watchful waiting | | | | | | | 44/74 (59)
Hammarén-Malmi 2006 | TT | [1, 4] | | | 1.0 (0.9) | | | 56/96 (58.3) | | 48/96 (50.0)
Hammarén-Malmi 2007 | TT AND adenoidectomy | [1, 4] | | | 1.1 (1.0) | | | 51/102 (50.0) | | 56/102 (54.9)
Hu-2015-26429601 | Total | [0.83, 10] | | | | | | 20/34 (59)
Hubbard 1985 4039792 | Early TT
Hubbard 1985 4039793 | Late TT
Kadhim 2007 17279052 | TT (Tympanostomy tubes)
Kadhim 2007 17279052 | TT AND adenoidectomy
Kobayashi 2012 22386275 | TT
Kobayashi 2012 22386276 | Control
Kremer 1979 456299 | Total | [0, >7] | | | | | | 152/243 (62.4)
Kuşcu 2015 26545930 | Early routine TT | 6.9 (4.3) | | | | | | 29/67 (43.3)
Kuşcu 2015 26545930 | TT at follow-up | 9.1 (3.7) | | | | | | 13/22 (59.1)
Kuşcu 2015 26545930 | No TT | 15.8 (8.9) | | | | | | 37/65 (56.9)
Li 2015 26281253a 2002–2012 China | Total | 5.9 [3, 14] | | | | | | 109/208 (52.4)
Li 2015 26281253b 2002–2012 China | Total | 5.7 [3, 14] | | | | | | 215/319 (67.4)
Mandel 1992 1565550 | Watchful waiting | [0.58, 12] | | | | | | 22/35 (62.9) | 16/33 (48.5)
Mandel 1992 1565550 | Myringotomy | [0.58, 12] | | | | | | 25/39 (64.1) | 22/36 (61.1)
Mandel 1992 1565550 | Myringotomy+ TT | [0.58, 12] | | | | | | 27/37 (73.0) | 14/35 (40.0)
Mandel 1989 2789777a | Control | [0.58, 12] | | | | | | 22/29 (75.9) | 11/29 (37.9)
Mandel 1989 2789777a | Myringotomy | [0.58, 12] | | | | | | 12/27 (44.4) | 6/27 (22.2)
Mandel 1989 2789777a | Myringotomy+ TT | [0.58, 12] | | | | | | 20/30 (66.7) | 11/30 (36.7)
Mandel 1989 2789777b | Myringotomy | [0.58, 12] | | | | | | 10/12 (83.3) | 2/12 (16.7)
Mandel 1989 2789777b | Myringotomy+ TT | [0.58, 12] | | | | | | 9/11 (81.8) | 1/11 (9.1)
Marshak 1980 6778336 | Total | [0, 8]
Maw 1999 10459904, Hall-2009-19260880, Wilks-2000-10944051 | TT | 2.96 (0.84) [1.17, 4.62] | | | 13% 1, 47% 2, 30% >=3 | | | | | 40/88 (47)
Maw 1999 10459904, Hall-2009-19260880, Wilks-2000-10944051 | Watchful waiting | 2.93 (0.87) [1.31, 4.69] | | | 17% 1, 39% 2, 44% >=3 | | | | | 35/72 (49)
Motta 2006 17465378 | Total | 66% <6 [2, 11] | | | | | | 114/193 (59)
MRC Multicentre Otitis Media Study Group (TARGET) 22443163 12680834 15373863 | TT AND adenoidectomy | 5.4 (0.86) | | 31.7 (6.4) | | | Mean reported hearing difficulty – RHD (sd) 14.0 (4.2) | 61/128 (48) | 81/125 (65) | 46/115 (40) | 120/120 (100)
MRC Multicentre Otitis Media Study Group 22443163 12680834 15373863 | TT | 5.2 (0.85) | | 32.2 (6.0) | | | Mean reported hearing difficulty – RHD (sd) 14.4 (4.1) | 60/126 (48) | 84/126 (67) | 35/110 (32) | 121/123 (98)
MRC Multicentre Otitis Media Study Group (TARGET) 22443163 12680834 15373863 | Watchful waiting | 5.2 (0.87) | | 33.5 (6.4) | | | Mean reported hearing difficulty – RHD (sd) 13.6 (4.5) | 62/122 (51) | 82/122 (67) | 29/101 (29) | 110/110 (100)
Niclasen-2016-27063746 | No TT | | | | | >= 4 | | 288/569 (50.6) | | Maternal: 250/569 (44.0); paternal 261/569 (45.8) | 0–3 years 521/569 (91.5); <3–6 years 558/569 (98.1)
Niclasen-2016-27063746 | TT (Tympanostomy tubes) | | | | | >= 4 | | 577/999 (57.8) | | Maternal: 452/999 (45.2); paternal 508/999 (50.9) | 0–3 years 924/999 (92.5); 3–6 years 982/999 (98.3)
Nguyen 2004 15126745 | TT | 3.4 [1.5, 9.5] | | | | | | 24/40 (60)
Nguyen 2004 15126745 | TT AND adenoidectomy | 4.5 [1.5, 9.5] | | | | | | 13/23 (57)
Paradise 2001 11309632, 2005 16093466, 2003 12897272, 2007 17229952, Johnston2004 15231974 | Early TT | | 39.7 % 1, 46.1 % 2, 14.2 % 3 | | | | | 115/204 (56.4)
Paradise 2001 11309632, 2005 16093466, 2003 12897272, 2007 17229952, Johnston2004 15231974 | Late TT | | 40.9 % 1, 47.7 % 2, 11.4 % 3 | | | | | 112/193 (58.0)
Peters 1994 8195687 | Control | 7.75 (2) | | | | | | 80/151 (53)
Peters 1994 8195687 | TT | 7.75 (1.9) | | | | | | 23/37 (62.2)
Popova 2010 20399511 | TT AND myringotomy AND adenoidectomy | 5 (1) [3.5, 7.2] | | | | | | 22/42 (52.4) | | 19/42 (45) | 40/42 (95)
Popova 2010 20399511 | Myringotomy AND adenoidectomy | 5.1 (3.8, 6.3) | | | | | | 20/36 (55.6) | | 31/36 (86) | 36/36 (100)
Rach 1991 2070526 | TT | [2, 4]
Rach 1991 2070526 | Control | [2, 4]
Reiter 2009 19929085 | Total | 8.5 (2.2) [0, 14] | | | | | | 28/53 (52.8)
Robson 1992 1431515 | TT | 6.3 [2, 13] | | | | | | 22/38 (57.9)
Robson 1992 1431515 | Control | 5.2 [0.5, 12] | | | | | | 14/32 (43.8)
Rovers 2000 10969126, 2001 11124783, 2001 11409855, 2001 11470387, Ingels 2005 16429748, Hartman 2001 11735817 | Total | 1.62 (1.3) | 0.75 | 44.9 (0.82) best ear | | | | 110/187 (58.8) | | | 49/187 (26.1)
Rovers 2000 10969126, 2001 11124783, 2001 11409855, 2001 11470387, Ingels 2005 16429748, Hartman 2001 11735817 | TT | 1.625 (1.7) | 0.75 | 46.4 (1.1) best ear [IQR 44.2, 48.6] | | | | 55/93 (59.1)
Rovers 2000 10969126, 2001 11124783, 2001 11409855, 2001 11470387, Ingels 2005 16429748, Hartman 2001 11735817 | Watchful waiting | 1.62 (1.9) | 0.75 | 43.4 (1.2) best ear [IQR 41.0, 45.8] | | | | 55/94 (58.5)
Stenstrom 2005 16330739 | Control | 12.3 (3.8) [8, 16] | | | | 3.1 (1.6) | Mean hearing loss at entry into RCT, PTA at 0.5, 1, 2, 4 kHz: mean: 33.4, sd: 11.9 | 14/27 (52) | | 14/27 (52) | 15/27 (56)
Stenstrom 2005 16330739 | TT | 11.6 (4.3) [8, 16] | | | | 1.9 (1.8) | Mean hearing loss at entry into RCT, PTA at 0.5, 1, 2, 4 kHz: mean: 28.7, sd: 13 | 23/38 (60) | | 16/38 (42) | 25/38 (66)
Velepic 2011 21397957 | TT AND adenoidectomy | 5.56
Velepic 2011 21397957 | Adenoidectomy | 5.44
Vlastos 2011 21205368 | TT AND adenoidectomy | 4.6 (1.1) [3, 7] | | 31.2 (3.9) [21, 39] | | | | 14/25 (56)
Vlastos 2011 21205368 | Myringotomy AND adenoidectomy | 4.4 (1.1) [3, 7] | | 32.7 (0.72) [27, 37] | | | | 15/27 (56)
Wolter 2012 22883987 | Total | Median: 6 [0.7, 17] | Median: 5.74
Xu 2003 12930655 | palate cleft repair | | | 43.9
Xu 2003 12930655 | palate cleft repair + TT | 4.8 [0.5, 10] | | 35.9
Yagi 1977 321716 | Total | Median: 6 [3, 12] | | 100% >20dB
Yousaf 2012 23855103 | Total | [2, 8] | | | | | | 38/62 (61.3)
Youssef 2013 24265883 | Total | 7.4 (2.0) | | | | | | 44/86 (51.1)
Youssef 2013 24265883 | TT + myringotomy +/− adenoidectoy | 7.8 (1.5)
Youssef 2013 24265883 | Laser myringotomy +/− adenoidectomy | 6.9 (2.3)
Schilder 1997 9372253 | TT | [2,4 ] | | 14.0 (12.8) | | | | 7/13 (53.8)
Schilder 1997 9372253 | control (no TT) | [2,4 ] | | 8.4 (7.7) | | | | 8/14 (57.1)

Table E2 Key Question 2 baselines

Study | Arm | Age (y), mean (range) | No. of OME episodes, mean | Males n/N (%) | In daycare n/N (%)
Casselbrant 1992 1565551 | Antibiotic prophylaxis (amoxicilin) | 43.3% 0.58–1.25, 40.0% 1.33–2.08, 16.7% 2.17–3^*^
Casselbrant 1992 1565551 | Placebo | 43.2% 0.58–1.25, 37.5% 1.33–2.08, 19.3% 2.17–3^*^
Casselbrant 1992 1565551 | TT | 45.3% 0.58–1.25, 34.9% 1.33–2.08, 19.8% 2.17–3^*^
El-Sayed 1996 | TT | 1.66 | | 17/31 (48.6)
El-Sayed 1996 | Antibiotic prophylaxis (sulfamethoxazole and trimethoprim) | 1.64
Gonzalez 1986 3537596 | TT | 1.68
Gonzalez 1986 3537596 | Antibiotic prophylaxis (sulfisoxazole) | 1.55
Gonzalez 1986 3537596 | Placebo | 1.39
Grindler 2014 24627408 | Total | 1.23 (0.38) | | 652/1208 (54.0) | 603/1006 (61.2)
Hammarén-Malmi 2006 | TT | [1,4] | | 56/96 (58.3)
Hammarén-Malmi 2006 | TT & Adenoidectomy | [1,4] | | 51/102 (50.0)
Kujala 2012 22466327, 24445832 | TT | 1.34 (0.33) | 6.7 | 36/100 (36)
Kujala 2012 22466327, 24445832 | TT & Adenoidectomy | 1.48 (0.36) | 6.3 | 41/100 (41)
Kujala 2012 22466327, 24445832 | Control | 1.33 (0.32) | 6.4 | 48/100 (48)
Mattila 2003 12578443 RCT | Total | 1.42 | 3.5 | 86/137 (62.8) | 35/137 (25.5)
Mattila 2003 12578443 RCT | TT + adenoidectomy | 1.39 | 3.5 | 47/74 (64) | 17/74 (22)
Mattila 2003 12578443 RCT | TT | 1.45 | 3.4 | 39/63 (62) | 18/63 (27)
Mattila 2003 12578443 NRCS | Total | 1.45 | 3.5 | 91/169 (53.8) | 43/169 (25.4)
Mattila 2003 12578443 NRCS | TT + adenoidectomy | 1.46 | 3.5 | 64/124 (52) | 31/124 (25)
Mattila 2003 12578443 NRCS | TT | 1.44 | 3.5 | 27/45 (60) | 12/45 (27)

* age given only in % in certain ranges

Table E3 Key Question 4 baselines

Study | Arm | Age (y), mean (range) | Males n/N (%) | Hx of adenoidectomy n/N (%) | Hx of tonsilectomy n/N (%) | Other
Becker 1987 3586818 | nonswimming | 4.9 (1, 14) | 24/30 | | | Sheehy Teflon collar button tubes
Becker 1987 3586819 | ear plugs | 6.3 (2, 14) | 17/23 (17) | | | Sheehy Teflon collar button tubes
Becker 1987 3586820 | no ear plugs | 5,9 (1.5, 13) | 10/32 (31) | | | Sheehy Teflon collar button tubes
Cohen 1994 8289048 | nonswimming | (3, 12) | 11/20 (55)
Cohen 1994 8289049 | swimming | (3, 12) | 12/22 (54.5)
el Silimy 1986 3780019 | nonswimming | 7 (4, 14) | 24/41 (58.5) | 18/41 (43.9) | 7/41 (17.1) | 16/41 (39%) bilateral grommets
el Silimy 1986 3780019 | swimming | 7 (4, 14) | 25/45 (55.6) | 20/45 (44.4) | 7/45 (15.6) | 18/45 (40%) bilateral grommets
Francois 1992 1485779. | nonswimming | 5.58 (overall)
Francois 1992 1485779. | swimming
Goldstein 2005 15689760 | ear plugs | 79%<=3 (0.5, 6)^*^ | 59/103 (57) | 24/103 (23)
Goldstein 2005 15689760 | no ear plugs | 81%<=3 (0.5, 6)^*^ | 60/98 (61) | 24/98 (24)
Kaufmann 1999 10546304 | Total | | | 15/86 (18) | 17/86 (20)
Kaufmann 1999 10546305 | no precautions | 5.3 (1.2, 15.6) | 30/47 (63)
Kaufmann 1999 10546306 | ear plugs | 5.8 (1.3, 12.3) | 11/16 (67)
Konradsson 1986 3784716 | nonswimming | (1, 15) | | nr | nr
Konradsson 1986 3784716 | swimming
Parker 1993 8024107 | nonswimming | 3.1 (0.58, 9)
Parker 1993 8024107 | swimming | 3.1 (0.25, 8)
Salata 1996 8607955 | Total | 2.67 (0.5, 12) | 238/399 (59.6) | 80/399 (20)
Salata 1996 8607956 | no precautions
Salata 1996 8607957 | ear drops
Salata 1996 8607958 | ear plugs
Salata 1996 8607959 | nonswimming
Sharma 1986 3472335 | nonswimmers | nr | nr
Sharma 1986 3472335 | swimmers | nr | nr
Smelt 1984 6538215 | Total | | | | | 39 had grommet resinsertions
Smelt 1984 6538215 | swimming

* age given only in % below/above 3 years

Table E4 Key Question 5 baselines

Study | Arm | Age (y), mean (SD) [range] | No. of previous episodes of otorrhea, mean (range) | Males n/N (%) | Cigarette smoke exposure n/N (%) | Daycare n/N (%) | Bilateral otorrhea n/N (%)
Dohar 1999 10326811 | antibiotic drop | 3.6 (2.7) | | 143/89 (62)
Dohar 1999 10326811 | historic controls | 3.6 (2.5) | | 309/175 (57)
Dohar 1999 10326811 | current usual treatment | 3.7 (2.5) | | 68/45 (67)
Dohar 2006 16880248 | antibiotic drop | 59% <2^*^ | | 39/20 (51) | | | 39/5 (13)
Dohar 2006 16880248 | oral antibiotic | 56% <2^*^ | | 41/22 (54) | | | 41/11 (27)
Goldblatt 1998 10190709 | antibiotic drop | 3.7 (2.46)
Goldblatt 1998 10190709 | oral antibiotic | 3.5 (2.62, p=0.521)
Heslop 2010 20979100 | antibiotic drop | 0.9 [0.6–9] (all) | | 40/68 (59) (all)
Heslop 2010 20979100 | oral antibiotic
Heslop 2010 20979100 | saline rinse
Roland 2003 14660913 | antibiotic-glucocorticoid drops | 2.57 (2.54) [0, 12] | | 87/46 (52.9) | | | 87/22 (25.3)
Roland 2003 14660913 | antibiotic drop | 2.26 (2.21) [0, 11] | | 80/41 (51.3) | | | 80/14 (17.5)
Roland 2004 (14702493, 15195060, Waycaster 2004_no PMID) | antibiotic-glucocorticoid drops | 49.2%<2, 49.8% 2–11, 1.0% >11^*^ | | 297/172 (57.9)
Roland 2004 14702493 | antibiotic drop | 49.0%<2, 51.0% 2–11^*^ | | 302/201 (66.6)
Ruohola 1999 10190921 | oral antibiotics and glucosteroids | [1.0,10.0] | | 23/14 (61)
Ruohola 1999 10190921 | oral antibiotics and palcebo | [1.0,5.8] | | 27/14 (52)
Ruohola 2003 12728089 | oral antibiotic | 2.25 (1.08) | 3.5 (IQR 3, 4.25) | 34/24 (71) | 34/19 (56) | 34/22 (65)
Ruohola 2003 12728089 | oral placebo | 1.75 (0.92) | 3 (IQR 2, 4) | 32/20 (63) | 32/16 (50) | 32/18 (56)
Strachan 2000 10865480 | antibiotic-glucocorticoid drops | 7.3 [2,25] (all)
Strachan 2000 10865480 | antibiotic-glucocorticoid spray
van Dongen 2014 24552319 (25896832) | antibiotic-glucocorticoid drops | 4.6 (2.1) | (0, 5) | 76/50 (66) | 76/13 (17) | 32/29 (91) | 76/14 (18)
van Dongen 2014 24552319 (25896832) | oral antibiotic | 4.4 (2.0) | (0, 5) | 77/40 (52) | 77/4 (5) | 33/27 (82) | 77/11 (14)
van Dongen 2014 24552319 (25896832) | watchful waiting | 4.4 (2.0) | (0, 3) | 77/43 (56) | 77/9 (12) | 31/25 (81) | 77/13 (17)

* age given only in % below/above threshold.