# Appendix D Arm Details

Table D1 Key Question 1 arm details

Table D2 Key Question 2 arm details

Table D3 Key Question 4 arm details

Table D4 Key Question 5 arm details