# Appendix C Study Design

Table C1 Key Question 1 design

Table C2 Key Question 2 design

Table C3 Key Question 4 design

Table 4 Key Question 5 design