# Appendix B Excluded Studies

Table B1 Excluded studies

PMID | Author(s) | Title | Journal | Exclusion Reason
| Diacova S. and Desvignes V. and Chiaburu A. and Chirtoca D. and Parii S. | Tympanostomy and adenoidectomy for treatment of otitis media in children | Archives of Disease in Childhood (2012) 97 SUPPL. 2 (A453). Date of Publication: October 2012 | Abstract
| Cheng L. and Chen S. and Cheng J. | Does tube type matter in posttympanostomy tube otorrhea? | Otolaryngology - Head and Neck Surgery (United States) (2014) 151:1 SUPPL. 1 (P147). Date of Publication: September 2014 | Abstract
| Chen S. and Cheng L. and Chen T. and Cheng J. and Cheng R. and Cheng D. | A review of 2399 ears for postmyringotomy tube otorrhea | Otolaryngology - Head and Neck Surgery (United States) (2012) 147 SUPPL. 2 (P130–P131). Date of Publication: August 2012 | Abstract
| Wang M.-C. | Ventilation tube insertions for pediatric otitis media with effusion: With adenoidectomy or not | Otolaryngology - Head and Neck Surgery (2011) 145 SUPPL. 2 (114). Date of Publication: August 2011 | Abstract
| Russell C. and Black O. and Dutt D. and Ray A. and Devlin M. and Wynne D. | Are ventilation tubes (grommets) in cleft children truly associated with increased complication rates? Results of a nested case control study of cleft and non-cleft children | British Journal of Oral and Maxillofacial Surgery (2012) 50 SUPPL. 1 (S2–S3). Date of Publication: June 2012 | Abstract
| Sidell D.R. and Hunter L. and Lin L. and Arjmand E.M. | Risk factors for hearing loss in the setting of pressure equalization tube placement in children | Otolaryngology - Head and Neck Surgery (United States) (2013) 149:2 SUPPL. 1 (P122). Date of Publication: September 2013 | Abstract
| Black O. and Dutt D. and Russell C. and Devlin M. and Ray A. and Wynne D. | Ventilation tubes in cleft children carry no higher risk of complication than their use in non cleft children: Results of a nested case control study | Clinical Otolaryngology (2012) 37 SUPPL. 1 (181–182). Date of Publication: July 2012 | Abstract
| Wolter N.E. and Dell S. and James A.L. and Campisi P. | Middle ear ventilation in children with primary ciliary dyskinesia | Otolaryngology - Head and Neck Surgery (2011) 145 SUPPL. 2 (111). Date of Publication: August 2011 | Abstract
| Diacova S. and Ababii I. and Maniuc M. and Danilov L. and Ababii P. and Diacova O. and McDonald T.J. | Modified surgery in children with persistent and recurrent otitis media | Archives of Disease in Childhood (2014) 99 SUPPL. 2 (A137). Date of Publication: October 2014 | Abstract
| Sobin, L. B. and Imbery, T. E. and Tatum, S. A. and Nicholas, B. D. and Koester, L. | Long-term otologic outcomes in patients with cleft palates | | Abstract
5567839 | J K Graham | Serous otitis media: complication of polyethylene tube insertion | Eye, ear, nose & throat monthly | Case report
12610892 | Pulec J.L. and Deguine C. | Long-term ventilating tube with tympanosclerosis | Ear, Nose and Throat Journal (2003) 82:1 (8). Date of Publication: 1 Jan 2003 | Case report
11011482 | Pulec J.L. and Deguine C. | Long-term ventilating tube with tympanosclerosis | Ear, Nose and Throat Journal (2000) 79:9 (680). Date of Publication: 2000 | Case report
13157738 | Armstrong B.W. | A new treatment for chronic secretory otitis media | Archives of otolaryngology (1954) 59:6 (653–654). Date of Publication: 1954 | Case report
5081036 | Gulzow J. | Observations during long-term drainage of the middle ear in chronic catarrh of the eustachian tube | Zeitschrift fur Laryngologie, Rhinologie, Otologie und ihre Grenzgebiete (1972) 51:10 (665–670). Date of Publication: Oct 1972 | Case report
10624048 | Deguine C. and Pulec J.L. | Grommet ventilation myringostomy with cholesteatoma | Ear, Nose and Throat Journal (1999) 78:12 (884). Date of Publication: 1999 | Case report
18357935 | Abbarah T. and Abbarah M.A. | Migration of T-tubes to the middle ear | Ear, Nose and Throat Journal (2008) 87:1. Date of Publication: January 2008 | Case report
16406076 | Riccardo D’Eredita and Udayan K Shah | Contact diode laser myringotomy for medium-duration middle ear ventilation in children | International journal of pediatric otorhinolaryngology | Cohort, N < 50
3218926 | C C Lau and K K Loh and N Kunaratnam | Middle ear diseases in cleft palate patients in Singapore | Annals of the Academy of Medicine, Singapore | Cohort, N < 50
5778864 | J H Per-Lee | Experiences with a “permanent” wide flange middle ear ventilation tube | The Laryngoscope | Cohort, N < 50
17440366 | Mohamed E Hassan and Sherif Askar | Does palatal muscle reconstruction affect the functional outcome of cleft palate surgery? | Plastic and reconstructive surgery | Cohort, N < 50
9041283 | M N Orlin and S K Effgen and S D Handler | Effect of otitis media with effusion on gross motor ability in preschool-aged children: preliminary findings | Pediatrics | Cohort, N < 50
7619414 | R W Force and M C Hart and S A Plummer and D A Powell and M C Nahata | Topical ciprofloxacin for otorrhea after tympanostomy tube placement | Archives of otolaryngology--head & neck surgery | Cohort, N < 50
6023618 | W L Draper | Secretory otitis media in children: a study of 540 children | The Laryngoscope | Cohort, N < 50
8504893 | M Selikowitz | Short-term efficacy of tympanostomy tubes for secretory otitis media in children with Down syndrome | Developmental medicine and child neurology | Cohort, N < 50
8551144 | D P Martin-Hirsch and C J Woodhead and C E Vize | Long-term ventilation of the middle ear using a tympanotomy technique | The Journal of laryngology and otology | Cohort, N < 50
10504021 | Y Iino and Y Imamura and S Harigai and Y Tanaka | Efficacy of tympanostomy tube insertion for otitis media with effusion in children with Down syndrome | International journal of pediatric otorhinolaryngology | Cohort, N < 50
3444993 | B Pérez Piñero and D López Aguado and M E Campos Bañales | [Tympanosclerosis and the ventilation tube] | Revue de laryngologie - otologie - rhinologie | Cohort, N < 50
7818639 | J G Gilbert | Swimming and grommets: a prospective survey | The New Zealand medical journal | Cohort, N < 50
7861292 | S Harigai | [Longitudinal studies in hearing-impaired children with Down’s syndrome] | Nihon Jibiinkoka Gakkai kaiho | Cohort, N < 50
14823225 | {CHAUVET} | [Consideration on the therapy of tubal otorrhea] | Gazette médicale de France | Cohort, N < 50
1742892 | P J Dawes and B J Bingham and R Rhys and M V Griffiths | Aspirating middle ear effusions when inserting ventilation tubes: does it influence postoperative otorrhoea, tube obstruction or the development of tympanosclerosis? | Clinical otolaryngology and allied sciences | Cohort, N < 50
19251534 | Mao-Che Wang and Chia-Yu Liu and An-Suey Shiao | Water penetration into middle ear through ventilation tubes in children while swimming | Journal of the Chinese Medical Association: JCMA | Cohort, N < 50
3418217 | C Watson and K S Mangat | A comparison of audiometric performance and complications of T tubes and Shepard grommets | The Journal of laryngology and otology | Cohort, N < 50
512469 | J Samuel and G Rosen and Y Vered | Use of middle ear ventilation tubes in recurrent acute otitis media | The Journal of laryngology and otology | Cohort, N < 50
2769837 | D McRae and D J Gatland and R Youngs and J Cook | Aspiration of middle ear effusions prior to grommet insertion an etiological factor in tympanosclerosis | The Journal of otolaryngology | Cohort, N < 50
3427802 | E Chevretton and B J Bingham and E Firman | The prevention of tympanic membrane perforation following the removal of long-term Paparella type II ventilation tubes | Clinical otolaryngology and allied sciences | Cohort, N < 50
3243014 | T H Lesser and K R Williams and D W Skinner | Tympanosclerosis, grommets and shear stresses | Clinical otolaryngology and allied sciences | Cohort, N < 50
4855092 | H L Wilson | The steel whisker tube in chronic secretory otitis media | Transactions - American Academy of Ophthalmology and Otolaryngology. American Academy of Ophthalmology and Otolaryngology | Cohort, N < 50
5550610 | N Shah | Use of grommets in ‘glue’ ears | The Journal of laryngology and otology | Cohort, N < 50
22796197 | Tuomas Klockars and Jorma Rautio | Early placement of ventilation tubes in cleft lip and palate patients: does palatal closure affect tube occlusion and short-term outcome? | International journal of pediatric otorhinolaryngology | Cohort, N < 50
1863436 | H C Pillsbury and J H Grose and J W Hall | Otitis media with effusion in children. Binaural hearing before and after corrective surgery | Archives of otolaryngology--head & neck surgery | Cohort, N < 50
14568787 | Joseph W Hall and John H Grose and Emily Buss and Madhu B Dev and Amelia F Drake and Harold C Pillsbury | The effect of otitis media with effusion on perceptual masking | Archives of otolaryngology--head & neck surgery | Cohort, N < 50
7190178 | Q Bailey | The Castelli membrane in the treatment of glue ear | The Journal of laryngology and otology | Cohort, N < 50
18072559 | Wei Li and Wei Shang and Ai-hua Yu and Xiao-heng Zhang and Yu-xin Liu and Xiu-ming Wan and Mu-yun Jia and Ning-yi Li | [Early treatment of middle ear disease in cleft palate infants] | Hua xi kou qiang yi xue za zhi = Huaxi kouqiang yixue zazhi = West China journal of stomatology | Cohort, N < 50
26949997 | Nihat Kılıç and Özgür Yörük and Songül Cömert Kılıç and Gülhan Çatal and Sezgin Kurt | Rapid maxillary expansion versus middle ear tube placement:Comparison of hearing improvements in children with resistance otitis media with effusion | Mar | Cohort, N < 50
2492178 | G A Gates and C A Avery and J C Cooper and T J Prihoda | Chronic secretory otitis media: effects of surgical management | The Annals of otology, rhinology & laryngology. Supplement | No extractable data
4040338 | G A Gates and C Wachtendorf and E M Hearne and G R Holt | Treatment of chronic otitis media with effusion: results of tympanostomy tubes | American journal of otolaryngology | No extractable data
3336263 | G A Gates and C A Avery and T J Prihoda | Effect of adenoidectomy upon children with chronic otitis media with effusion | The Laryngoscope | No extractable data
11678951 | {Medical Research Council Multicentre Otitis Media Study Group} | Surgery for persistent otitis media with effusion: generalizability of results from the UK trial (TARGET). Trial of Alternative Regimens in Glue Ear Treatment | Clinical otolaryngology and allied sciences | No extractable data
11434951 | M M Rovers and G A Zielhuis and K Bennett and M Haggard | Generalisability of clinical trials in otitis media with effusion | International journal of pediatric otorhinolaryngology | No extractable data
18685496 | {MRC Multicentre Otitis Media Study Group} | An extension of the Jerger classification of tympanograms for ventilation tube patency- -specification and evaluation of equivalent ear-canal volume criteria | Ear and hearing | No extractable data
12363423 | A A Maheshwar and M A P Milling and M Kumar and M I Clayton and A Thomas | Use of hearing aids in the management of children with cleft palate | International journal of pediatric otorhinolaryngology | No extractable data
25677370 | Joong Ho Ahn and Woo Seok Kang and Ji Heui Kim and Kyung S Koh and Tae Hyun Yoon | Critical reassessment of the probability of receiving additional ventilation tube insertion for recurrent otitis media with effusion in children with a cleft palate | Acta oto-laryngologica | No extractable data
3818186 | H Hafner and I Anteby and H Pratt and M Goldsher and R Shenhav and H Z Joachims | Auditory brainstem evoked potentials in evaluating the efficacy of surgical ventilation of the middle ear | International journal of pediatric otorhinolaryngology | No extractable data
10542923 | J D Hern and D A Jonathan | Insertion of ventilation tubes: does the site matter? | Clinical otolaryngology and allied sciences | No extractable data
8741962 | L L Hunter and R H Margolis and J R Rykken and C T Le and K A Daly and G S Giebink | High frequency hearing loss associated with otitis media | Ear and hearing | No extractable data
3818185 | I Anteby and H Hafner and H Pratt and N Uri | Auditory brainstem evoked potentials in evaluating the central effects of middle ear effusion | International journal of pediatric otorhinolaryngology | No extractable data
6778358 | B Hussl and K Welzl-Mueller | Secretory otitis media and mastoid pneumatization | The Annals of otology, rhinology & laryngology. Supplement | No extractable data
24243868 | Christina T Ryborg and Jens Søndergaard and Jørgen Lous and Anders Munck and Pia V Larsen and Janus L Thomsen | Quality of life in children with otitis media--a cohort study | Family practice | No extractable data
11074114 | Y Rakover and K Keywan and G Rosen | Comparison of the incidence of cholesteatoma surgery before and after using ventilation tubes for secretory otitis media | International journal of pediatric otorhinolaryngology | No extractable data
5795401 | Paradise J.L. and Bluestone C.D. and Felder H. | The universality of otitis media in 50 infants with cleft palate | Pediatrics (1969) 44:1 (463–471). Date of Publication: 1969 | No extractable data
| Morales D.S.R. and Testa J.R.G. and Guilherme A. and Fukuda Y. | Permanence time of 164 ventilation tympanic tubes in 82 cleft palate pacients | Revista Brasileira de Otorrinolaringologia (2001) 67:1 (22–27). Date of Publication: 2001 | No extractable data
22531243 | Van Dongen T.M.A. and Schilder A.G.M. and Manders L.A. and Van Der Veen E.L. and Van Der Heijden G.J.M.G. | Good agreement between parents and physician in the assessment of ear discharge in children | Pediatric Infectious Disease Journal (2012) 31:8 (868–869). Date of Publication: August 2012 | No extractable data
4666579 | King J.T. | Modified exploratory ulterior tympanotomy in chronic secretory otitis media in children | Trans. Amer. Acad. Ophthal. Otolaryng. (1972) 76:5 (1292–1295). Date of Publication: 1972 | No outcomes of interest
25676152 | Christian Hamilton Heidemann and Henrik Hein Lauridsen and Anette Drøhse Kjeldsen and Christian Emil Faber and Eva Charlotte Jung Johansen and Christian Godballe | Quality-of-Life Differences among Diagnostic Subgroups of Children Receiving Ventilating Tubes for Otitis Media | Oct | No outcomes of interest
12622537 | Mark Boston and Joe McCook and Bonnie Burke and Craig Derkay | Incidence of and risk factors for additional tympanostomy tube insertion in children | Archives of otolaryngology--head & neck surgery | No outcomes of interest
8877207 | A R Maw and R Bawden and L O’Keefe and P Gurr | Does the type of middle ear aspirate have any prognostic significance in otitis media with effusion in children? | Clinical otolaryngology and allied sciences | No outcomes of interest
21106257 | Richard M Rosenfeld and David W Jang and Konstantin Tarashansky | Tympanostomy tube outcomes in children at-risk and not at-risk for developmental delays | International journal of pediatric otorhinolaryngology | No outcomes of interest
22183901 | Nathan S Alexander and Brian D Kulbersh and C Hope Heath and Renee A Desmond and Eric Caron and Audie L Woolley and Jimmy Scott Hill and W Peyton Shirley and Brian J Wiatrak | MRSA and non-MRSA otorrhea in children: a comparative study of clinical course | Archives of otolaryngology--head & neck surgery | No outcomes of interest
12117333 | Michele Richards and Carla Giannoni | Quality-of-life outcomes after surgical intervention for otitis media | Archives of otolaryngology--head & neck surgery | No outcomes of interest
12439177 | Rahmi Kiliç and Mustafa A Safak and Ali Ozdek and Hakan Göçmen and Dilek Kiliç and Erdal Samim | Effect of 23 valent pneumococcal polysaccharide and Haemophilus influenza conjugated vaccines on the clinical course of otitis media with effusion | The Laryngoscope | No outcomes of interest
6539321 | O G Neumann and R Laszig | [Diagnosis and therapy of seromucous otitis. Experience with 2766 operations on children] | HNO | No outcomes of interest
2254809 | M Suetake and T Kobayashi and T Takasaka and H Shinkawa | [Middle ear air volume and prognosis of secretory otitis media] | Nihon Jibiinkoka Gakkai kaiho | No outcomes of interest
8260856 | T C Theoharides and S S Manolidis and H Vliagoftis and L S Manolidis | Treatment of secretory otitis media with local instillation of hydroxyzine | International archives of allergy and immunology | No outcomes of interest
8026089 | A R Maw and R Bawden | Factors affecting resolution of otitis media with effusion in children | Clinical otolaryngology and allied sciences | No outcomes of interest
24983459 | Mao-Che Wang and Ying-Piao Wang and Chia-Huei Chu and Tzong-Yang Tu and An-Suey Shiao and Pesus Chou | The protective effect of adenoidectomy on pediatric tympanostomy tube re-insertions: a population-based birth cohort study | PloS one | No outcomes of interest
7218998 | B F Jaffe | Are water and tympanotomy tubes compatible? | The Laryngoscope | No outcomes of interest
1787379 | A Golz and S T Westerman and L M Gilbert and H Z Joachims and A Netzer | Effect of middle ear effusion on the vestibular labyrinth | The Journal of laryngology and otology | No outcomes of interest
3974389 | B F Lounsbury | Swimming unprotected with long-shafted middle ear ventilation tubes | The Laryngoscope | No outcomes of interest
9596366 | A Golz and B Angel-Yeger and S Parush | Evaluation of balance disturbances in children with middle ear effusion | International journal of pediatric otorhinolaryngology | No outcomes of interest
17645949 | Yan Chow and David A M Wabnitz and John Ling | Quality of life outcomes after ventilating tube insertion for otitis media in an Australian population | International journal of pediatric otorhinolaryngology | No outcomes of interest
20504840 | Petri S Mattila and Sari Hammarén-Malmi and Harri Saxen and Tarja Kaijalainen and Helena Käyhty and Jussi Tarkkanen | Adenoidectomy and nasopharyngeal carriage of Streptococcus pneumoniae in young children | Archives of disease in childhood | No outcomes of interest
7193427 | H H Elverland and I W Mair and O K Haugeto and K E Schrøder | Influence of adenoid hypertrophy on secretory otitis media | The Annals of otology, rhinology, and laryngology | No outcomes of interest
23917659 | Leticia Reis Borges and Jorge Rizzato Paschoal and Maria Francisca Colella-Santos | (Central) auditory processing: the impact of otitis media | Clinics (São Paulo, Brazil) | No outcomes of interest
| Donaldson J.A. | The role of artificial(bullet) eustaciiian tube in cleft palate patients | Cleft Palate Journal (1966) 3:1 (61–66). Date of Publication: 1966 | No outcomes of interest
26218381 | Lauren A Hanes and Amanda Murphy and Jill E Hatchette and Raylene Delorey and Kenneth L Wilson and Paul Hong and Michael Bezuhly | Chronic Otitis Media with Effusion Is Associated with Increased Risk of Secondary Speech Surgery | Aug | No outcomes of interest
2563465 | G A Zielhuis and G H Rach and P van den Broek | Screening for otitis media with effusion in preschool children | Lancet (London, England) | No outcomes of interest
1571119 | G S Giebink and K Daly and D J Buran and M Satz and T Ayre | Predictors for postoperative otorrhea following tympanostomy tube insertion | Archives of otolaryngology--head & neck surgery | No outcomes of interest
26454528 | P Niemi and J Numminen and M Rautiainen and M Helminen and H Vinkka-Puhakka and T Peltomäki | The effect of adenoidectomy on occlusal development and nasal cavity volume in children with recurrent middle ear infection | International journal of pediatric otorhinolaryngology | No outcomes of interest
17403263 | S Sood and A Waddell | Accurate consent for insertion and later removal of grommets | The Journal of laryngology and otology | No outcomes of interest
10208683 | C G Gourin and R N Hubbell | Otorrhea after insertion of silver oxide-impregnated silastic tympanostomy tubes | Archives of otolaryngology--head & neck surgery | No outcomes of interest
17043261 | Erwin L van der Veen and Anne G M Schilder and Niels van Heerbeek and Monique Verhoeff and Gerhard A Zielhuis and Maroeska M Rovers | Predictors of chronic suppurative otitis media in children | Archives of otolaryngology--head & neck surgery | No outcomes of interest
22835927 | Petri S Mattila and Sari Hammarén-Malmi and Harri Saxen and Tarja Kaijalainen and Helena Käyhty and Jussi Tarkkanen | Adenoidectomy in young children and serum IgG antibodies to pneumococcal surface protein A and choline binding protein A | International journal of pediatric otorhinolaryngology | No outcomes of interest
14643475 | Joseph Dohar | Microbiology of otorrhea in children with tympanostomy tubes: implications for therapy | International journal of pediatric otorhinolaryngology | No outcomes of interest
19131420 | P S Mattila and S Hammarén-Malmi and A S Pelkonen and L P Malmberg and M J Mäkelä and H Saxen and J Tarkkanen | Effect of adenoidectomy on respiratory function: a randomised prospective study | Archives of disease in childhood | No outcomes of interest
3201954 | I Augustsson and C Nilsson and P Neander | Do we treat “the right” children with secretory otitis media at the ENT clinic? | Acta oto-laryngologica. Supplementum | No outcomes of interest
25764097 | Thijs M A van Dongen and Roderick P Venekamp and Annemarie M J Wensing and Debby Bogaert and Elisabeth A M Sanders and Anne G M Schilder | Acute otorrhea in children with tympanostomy tubes: prevalence of bacteria and viruses in the post-pneumococcal conjugate vaccine era | The Pediatric infectious disease journal | No outcomes of interest
9176804 | Y Rakover and K Keywan and G Rosen | Safety of topical ear drops containing ototoxic antibiotics | The Journal of otolaryngology | No outcomes of interest
9288214 | H Valtonen and Y Qvarnberg and H Puhakka and J Nuutinen | Early post-tympanostomy otorrhea in children under 17 months of age | Acta oto-laryngologica | No outcomes of interest
14740537 | Ivan Baljosević and Vladan Subarević and Nikola Mircetić and Jovana Jecmenica and Jovica Karanov and Zorica Vasiljević | [Suppurative middle ear infection as a complication after tympanostomy tube placement] | Medicinski pregled | No outcomes of interest
3670236 | M Stura and G Ivani | [Insertion of trans-tympanic drainage in muco-gelatinous otitis in children] | Minerva pediatrica | No outcomes of interest
17178938 | David M Poetker and D Richard Lindstrom and Nalin J Patel and Stephen F Conley and Valerie A Flanary and T Roxanne Link and Joseph E Kerschner | Ofloxacin otic drops vs neomycin-polymyxin B otic drops as prophylaxis against early postoperative tympanostomy tube otorrhea | Archives of otolaryngology--head & neck surgery | No outcomes of interest
2128487 | K Roos and G Granström and G Karlsson and L Lind and S Olling and U Renvall | Ear discharge after insertion of transmyringeal tubes | International journal of pediatric otorhinolaryngology | No outcomes of interest
12161732 | Gordon J Siegel and Rakesh K Chandra | Laser office ventilation of ears with insertion of tubes | Otolaryngology--head and neck surgery: official journal of American Academy of Otolaryngology-Head and Neck Surgery | No outcomes of interest
5249846 | M S Robertson | Chronic secretoty otitis media: treatment with trans-tympanic indwelling polythene tubes | The New Zealand medical journal | No outcomes of interest
8745020 | K A Daly and G S Giebink and B Lindgren and R H Margolis and D Westover and L L Hunter and C T Le and D Buran | Randomized trial of the efficacy of trimethoprim-sulfamethoxazole and prednisone in preventing post-tympanostomy tube morbidity | The Pediatric infectious disease journal | No outcomes of interest
16172353 | Brechtje de Beer and Ad Snik and Anne G M Schilder and Kees Graamans and Gerhard A Zielhuis | The effect of otitis media in childhood on the development of middle ear admittance on reaching adulthood | Archives of otolaryngology--head & neck surgery | No outcomes of interest
1479274 | M A Salam and C Wengraf | Glue under pressure: a bad prognostic sign for recurrence of otitis media with effusion | The Journal of laryngology and otology | No outcomes of interest
23379112 | Min Huang and Sijun Zhao and Yun Li and Xiangyue Peng and Yuting Kuang and Songliang Long | [The effect of tympanostomy tube surgery in cleft palate children with secretory otitis media] | Lin chuang er bi yan hou tou jing wai ke za zhi = Journal of clinical otorhinolaryngology, head, and neck surgery | No outcomes of interest
3713407 | G A Gates and C Avery and T J Prihoda and G R Holt | Post-tympanostomy otorrhea | The Laryngoscope | No outcomes of interest
16510637 | Niels van Heerbeek and Masja Straetemans and Selma P Wiertsema and Koen J A O Ingels and Ger T Rijkers and Anne G M Schilder and Elisabeth A M Sanders and Gerhard A Zielhuis | Effect of combined pneumococcal conjugate and polysaccharide vaccination on recurrent otitis media with effusion | Pediatrics | No outcomes of interest
| Coates H. | Preventing and treating grommet tube otorrhoea | Medicine Today (2002) 3:10 (77–79). Date of Publication: 1 Oct 2002 | No outcomes of interest
| Coates H. and Sashikumar A. | A prospective clinical trial of antibiotic/steroid ear drops and incidence of infection following ventilation tube insertion | Journal of the Otolaryngological Society of Australia (1990) 6:4 (272–274). Date of Publication: 1990 | No outcomes of interest
| Becker C.G. and Da Silva A.L. and Guimaraes R.E.S. and Becker H.M.G. and Barra I.M. and Oliveira W.D. | Surgical treatment of otitis media with effusion: Ventilation tube versus topical application of mitomycin C | Revista Brasileira de Otorrinolaringologia (2003) 69:4 (513–519). Date of Publication: 2003 | No outcomes of interest
| Raja H. and Williams J. and Tzifa K. | Audiology following up grommets can improve efficiency and finances for ENT | Clinical Otolaryngology (2012) 37 SUPPL. 1 (176). Date of Publication: July 2012 | No outcomes of interest
25554572 | Axel Håkansson and Rut Florentzson and Lisa Tuomi and Caterina Finizia | Transmyringeal ventilation tube treatment in children: hearing outcome after 10 years | Feb | No outcomes of interest
26985629 | Eric A Mair and Albert H Park and Debra Don and Jeffrey Koempel and Moraye Bear and Carl LeBel | Safety and Efficacy of Intratympanic Ciprofloxacin Otic Suspension in Children With Middle Ear Effusion Undergoing Tympanostomy Tube Placement: Two Randomized Clinical Trials | May | No outcomes of interest
26611339 | Jacob W Zeiders and Charles A Syms and Mary T Mitskavich and David M Yen and Daniel T Harfe and Ryan D Shields and Brent J Lanier and Andrew R Gould and Jason Mouzakes and C Layton Elliott | Tympanostomy tube placement in awake, unrestrained pediatric patients: A prospective, multicenter study | Dec | No outcomes of interest
26454528 | P Niemi and J Numminen and M Rautiainen and M Helminen and H Vinkka-Puhakka and T Peltomäki | The effect of adenoidectomy on occlusal development and nasal cavity volume in children with recurrent middle ear infection | Dec | No outcomes of interest
11797262 | C R Cannon and W H Replogle | Otorrhea following Ultracil ear tube insertion | Journal of the Mississippi State Medical Association | No outcomes of interest
3517534 | T J Balkany and I K Arenberg and R L Steenerson | Ventilation tube surgery and middle ear irrigation | The Laryngoscope | No outcomes of interest
17049144 | Marisol Carignan and Dominique Dorion and Marie-France Stephenson and Michel Rouleau | First myringotomy with insertion of a modified Goode T-Tube: changing the perforation paradigm | The Journal of otolaryngology | No outcomes of interest
21777983 | David M Gleinser and Hilda H Kriel and Shraddha Mukerji | The relationship between repeat tympanostomy tube insertion and adenoidectomy | International journal of pediatric otorhinolaryngology | No outcomes of interest
7550814 | D A Clements and L Langdon and C Bland and E Walter | Influenza A vaccine decreases the incidence of otitis media in 6- to 30-month-old children in day care | Archives of pediatrics & adolescent medicine | No outcomes of interest
| Elverland H.H. and Haugeto O.K. and Andersen L. | Adenoidectomy and secretory otitis media | Acta Oto-Laryngologica (1982) 94:Suppl. 386 (134–136). Date of Publication: 1982 | No outcomes of interest
26545794 | Oumama El Ezzi and Georges Herzog and Martin Broome and Chantal Trichet-Zbinden and Judith Hohlfeld and Jacques Cherpillod and Anthony S de Buys Roessingh | Grommets and speech at three and six years in children born with total cleft or cleft palate | Dec | No outcomes of interest
25598382 | Wan X. and Yang J. and Jia H. | Efficacy of surgery, recurrence factors and treatment strategies of otitis media with effusion in children | Zhonghua er bi yan hou tou jing wai ke za zhi = Chinese journal of otorhinolaryngology head and neck surgery (2014) 49:11 (964–967). Date of Publication: 1 Nov 2014 | No primary data
8656164 | A Adelman | Water precautions in children with tympanostomy tubes | The Journal of family practice | No primary data
15851429 | M M Rovers and N Black and G G Browning and R Maw and G A | Grommets in otitis media with effusion: an individual patient data meta-analysis | Archives of disease in childhood | No primary data
6974210 | Zielhuis and M P Haggard L J Hall | Chronic serous otitis media | The Journal of the Kentucky Medical Association | No primary data
6357648 | T Lildholdt | Secretory otitis media. The significance of negative middle ear pressure and the results of a controlled study of ventilation tubes | Danish medical bulletin | No primary data
11509152 | M B Stephens | Does delaying placement of tympanostomy tubes have an adverse effect on developmental outcomes in children with persistent middle ear effusions? | The Journal of family practice | No primary data
1110316 | L W Pratt | The use of equalization tubes in nonsuppurative otits media | The Journal of the Maine Medical Association | No primary data
8461735 | A F Bisset | Persistent glue ear in children | BMJ (Clinical research ed.) | No primary data
16299942 | | Early tymp tubes do not improve outcomes after 3+ years | The Journal of family practice | No primary data
7017311 | D E Gebhart | Tympanostomy tubes in the otitis media prone child | The Laryngoscope | No primary data
24438691 | Chantal W B Boonacker and Maroeska M Rovers and George G Browning and Arno W Hoes and Anne G M Schilder and Martin J Burton | Adenoidectomy with or without grommets for children with otitis media: an individual patient data meta-analysis | Health technology assessment (Winchester, England) | No primary data
8404550 | C Deguine and J L Pulec | Long-term ventilation myringostomy | Ear, nose, & throat journal | No primary data
567665 | M E Alberts | Ventilation of glue ears | Journal of the Iowa Medical Society | No primary data
8482269 | M D Poole | Treatment of otorrhea associated with tubes or perforations | Ear, nose, & throat journal | No primary data
24524194 | Chin-Lung Kuo and Yuan-Heng Tsao and An-Suey Shiao | Critical reassessment of the probability of receiving additional ventilation tube insertion for recurrent otitis media with effusion in children with cleft palate | Acta oto-laryngologica | No primary data
880099 | D W Johnson and R H Mathog and R H Maisel | Tympanostomy tube protection with ear plugs | Archives of otolaryngology (Chicago, Ill.: 1960) | No primary data
3522165 | | The surgical management of glue ear | Drug and therapeutics bulletin | No primary data
3743473 | I J Moore and G F Moore and A J Yonkers | Otitis media in the cleft palate patient | Ear, nose, & throat journal | No primary data
1009868 | B K Devgan | Spoon-bobbin drain tube | Ear, nose, & throat journal | No primary data
11115295 | C Giannoni | Swimming with tympanostomy tubes | Archives of otolaryngology--head & neck surgery | No primary data
853006 | R Reck | A rare complication of use of the middle ear ventilation tube (PVC) | HNO | No primary data
17537888 | Morten Lindbaek | Prompt insertion of tympanostomy tubes in infants and toddlers with persistent middle ear effusion did not improve developmental outcomes at 9–11 years of age | Evidence-based medicine | No primary data
4079654 | V Cerkez | [Treatment of secretory otitis: medical or surgical therapy?] | Liječnički vjesnik | No primary data
1416480 | A Clarós | [Otitis media. Surgical treatment] | Anales españoles de pediatría | No primary data
8494594 | P Federspil | [Treatment of “suppurating ear” with intact middle ear tubes] | Laryngo- rhino- otologie | No primary data
6778337 | J L Paradise and C D Bluestone and K D Rogers and F H Taylor | Efficacy of adenoidectomy in recurrent otitis media. Historical overview and preliminary results from a randomized, controlled trial | The Annals of otology, rhinology & laryngology. Supplement | No primary data
12107957 | Jørgen Lous and Maj-Britt Glenn Lauritsen | [Inserted tympanostomy tube in prolonged secretory otitis has no effect on language development] | Ugeskrift for laeger | No primary data
1161091 | R J van der Wal | [Swimming with perforated tympanic membrane?] | Nederlands tijdschrift voor geneeskunde | No primary data
6576790 | N Fernández-Blasini | [Tonsils, adenoids and related problems: use and abuse of ventilation tubes] | Boletín de la Asociación Médica de Puerto Rico | No primary data
1535965 | C Chavanne | [Surgical treatment of secretory otitis media in children] | Revue médicale de la Suisse romande | No primary data
| Poole M.D. | Bacterial resistance to quinolone otic drops is nearly zero | Ear, Nose and Throat Journal (2007) 86:11 SUPPL. 1 (13–14). Date of Publication: November 2007 | No primary data
4819101 | Mawson S.R. | Middle ear effusions: therapy and clinical results | Annals of Otology, Rhinology and Laryngology (1974) 83:11 sup (71–72). Date of Publication: 1974 | No primary data
| Brown M.W. | Glue ear | South Australian Clinics (1975) 7:1 (69–71). Date of Publication: 1975 | No primary data
| Husson Y. and Troy C. | Tubal catarrh | Concours Medical (1975) 97:33 (5041–5048). Date of Publication: 1975 | No primary data
11115297 | Brodsky L. | Swimming with tympanostomy tubes: The controversy continues | Archives of Otolaryngology - Head and Neck Surgery (2000) 126:12 ([d]1509). Date of Publication: 2000 | No primary data
6077690 | Deutsch H.J. | Serous otitis media. An effective, practical approach to diagnosis and therapy of this most common cause of conductive loss of hearing in children | Penn. Med. (1967) 70:11 (53–55). Date of Publication: 1967 | No primary data
5773899 | Cross J.P. | The expanding role of tympanostomy tubes | Virginia Med.Mth. (1969) 96:2 (387–393). Date of Publication: 1969 | No primary data
1549417 | Landay S.E. and Schwartz R.H. | Recommendations for swimming for children with ear infection and/or associated complications | Pediatric Infectious Disease Journal (1992) 11:1 (58–59). Date of Publication: 1992 | No primary data
| Mees K. | The use of grommets in serous otitis media | Munchener Medizinische Wochenschrift (1982) 124:11 (39–44). Date of Publication: 1982 | No primary data
| Namyslowski G. and Gierek T. and Pilch J. and Iwanowski P. | Tarflen tubes for draining of tympanic cavity | Otolaryngologia Polska (1987) 41:5 ( 334–338). Date of Publication: 1987 | No primary data
| Dohar J.E. | Are topical quinolones safe for middle ear use in children? | Ear, Nose and Throat Journal (2006) 85:10 SUPPL. 1 (6–7). Date of Publication: October 2006 | No primary data
| Rovers M.M. and Krabbe P.F. and Straatman H. | Ventilation tubes did not improve quality of life in persistent otitis media with effusion | Evidence-Based Medicine (2001) 6:4 (121). Date of Publication: 2001 | No primary data
8486102 | Pulec J.L. and Deguine C. | Secretory otitis media (Glue Ear) | Ear, Nose and Throat Journal (1993) 72:4 (254). Date of Publication: 1993 | No primary data
25695362 | Chin-Lung Kuo | A critical appraisal of ventilation tube insertion in children with cleft palate | Feb | No primary data
25677370 | Joong Ho Ahn and Woo Seok Kang and Ji Heui Kim and Kyung S Koh and Tae Hyun Yoon | Critical reassessment of the probability of receiving additional ventilation tube insertion for recurrent otitis media with effusion in children with a cleft palate | May | No primary data
24524194 | Chin-Lung Kuo and Yuan-Heng Tsao and An-Suey Shiao | Critical reassessment of the probability of receiving additional ventilation tube insertion for recurrent otitis media with effusion in children with cleft palate | May | No primary data
| Outhoff, K. | Grommets | | No primary data
26216610 | Del Mar, C. D. and Hoffmann, T. | Autoinflation: An effective nondrug intervention for glue ear | | No primary data
| Anonymous | Erratum to: Long term complications of ventilation tube insertion in children with otitis media with effusion: Vojnosanit Pregl 2015; 72(1): 40–43 | | No primary data
1102070 | Alejandro Hoberman | Efficacy of Tympanostomy Tubes for Children With Recurrent Acute Otitis Media | | No primary data
16480003 | Takeshi Yagi and Ken Hayashi and Hisayoshi Shikii and Yuko Miyamoto and Makoto Oda and Atsushi Shinkawa | [Effect of volume reduction surgery by radiofrequency for enlarged adenoid causing recurrent otitis media with effusion] | Nihon Jibiinkoka Gakkai kaiho | Not intervention of interest
25215630 | Kavita Dedhia and Sukgi Choi and David H Chi | Management of refractory tympanostomy tube otorrhea with ear wicks | Mar | Not intervention of interest
25873182 | Mirjana Kostić and Ksenija Ribarić Jankes and Robert Trotić and Mihael Ries and Branka Ledić and Vladimir Bedeković | Clinical and audiological findings in children with acute otitis media | Jul | Not intervention of interest
26281252 | Wenrong Jiang and Tao He and Qian Zheng and Wei Zheng and Bing Shi and Chao Yang and Chenghao Li | [Integrated assessment of middle ear dysfunction in cleft palate patients and optimization of therapeutic schedule] | Hua xi kou qiang yi xue za zhi = Huaxi kouqiang yixue zazhi = West China journal of stomatology | Not intervention of interest
6540371 | S J de Vries and R Wentges | [Ear drum grommets and swimming] | Nederlands tijdschrift voor geneeskunde | Not intervention of interest
10406313 | O C Ilicali and N Keleş and K Değer and I Savaş | Relationship of passive cigarette smoking to otitis media | Archives of otolaryngology--head & neck surgery | Not intervention of interest
9253394 | S M Marcus | Assessing non-consent bias with parallel randomized and nonrandomized clinical trials | Journal of clinical epidemiology | Not intervention of interest
25873182 | Mirjana Kostić and Ksenija Ribarić Jankes and Robert Trotić and Mihael Ries and Branka Ledić and Vladimir Bedeković | Clinical and audiological findings in children with acute otitis media | Acta oto-laryngologica | Not intervention of interest
3701198 | E Vartiainen and J Kärjä and S Karjalainen | Surgery of chronic otitis media in young patients | The Journal of laryngology and otology | Not intervention of interest
962698 | M C Gydé | When the weeping stopped: an otologist views otorrhea and gentamicin | Archives of otolaryngology (Chicago, Ill.: 1960) | Not intervention of interest
14551787 | Elbieta Hassmann and Boena Skotnicka and Maria Baczek and Małgorzata Piszcz | Laser myringotomy in otitis media with effusion: long-term follow-up | European archives of oto-rhino-laryngology: official journal of the European Federation of Oto-Rhino-Laryngological Societies (EUFOS): affiliated with the German Society for Oto- Rhino-Laryngology - Head and Neck Surgery | Not intervention of interest
25274185 | A Qureishi and G Garas and A Mallick and D Parker | The psychosocial impact of hearing aids in children with otitis media with effusion | The Journal of laryngology and otology | Not intervention of interest
21362577 | Chang Ho Lee and Chan Kee Yoo and Jong Eui Hong and Hong Joong Kim and Dae Geun Lim and Kwang Joong Kim | Resolved effusion on myringotomy: a study of dry tap without general anesthesia | International journal of pediatric otorhinolaryngology | Not intervention of interest
20058316 | Katrina Spilsbury and Ian Miller and James B Semmens and Francis J Lannigan | Factors associated with developing cholesteatoma: a study of 45,980 children with middle ear disease | The Laryngoscope | Not population of interest
19091429 | Yun Shan Phua and Lesley J Salkeld and Tristan M B de Chalain | Middle ear disease in children with cleft palate: protocols for management | International journal of pediatric otorhinolaryngology | Not population of interest
4470582 | I S Thomson | Exudative otitis media, grommets and cholesteatoma | The Journal of laryngology and otology | Not population of interest
7098686 | H Heumann and E Steinbach and R Seuffer | [A clinical and experimental study on precious metal ventilation tubes (author’s transl)] | Laryngologie, Rhinologie, Otologie | Not population of interest
| Fujita A. and Kurata K. and Takahashi H. and Takagita S. | Clinical efficacy of clarithromycin treatment of refractory otitis media with effusion | Practica Otologica (1994) 87:9 (1287–1291). Date of Publication: 1994 | Not population of interest
7642987 | H L Tay and R P Mills | Tympanic membrane atelectasis in childhood otitis media with effusion | The Journal of laryngology and otology | Not population of interest
6380828 | C H Bulman and S J Brook and M G Berry | A prospective randomized trial of adenoidectomy vs grommet insertion in the treatment of glue ear | Clinical otolaryngology and allied sciences | Per ear assignment
6598263 | T Lildholdt | Consequences of ventilation tube treatment | Acta oto-laryngologica. Supplementum | Per ear assignment
2037414 | M J Cunningham and E H Harley | Preventing perioperative obstruction of tympanostomy tubes: a prospective trial of a simple method | International journal of pediatric otorhinolaryngology | Per ear assignment
5070299 | D Kilby and S H Richards and G Hart | Grommets and glue ears: two-year results | The Journal of laryngology and otology | Per ear assignment
3389234 | A R Maw | Tonsils and adenoids. Their relation to secretory otitis media | Advances in oto-rhino-laryngology | Per ear assignment
9199524 | M Gaihede and T Lildholdt and J Lunding | Sequelae of secretory otitis media: changes in middle ear biomechanics | Acta oto-laryngologica | Per ear assignment
2394020 | A J Parker and A R Maw and J E Powell | Intra-tympanic membrane bleeding after grommet insertion and tympanosclerosis | Clinical otolaryngology and allied sciences | Per ear assignment
3524910 | N Black and J Crowther and A Freeland | The effectiveness of adenoidectomy in the treatment of glue ear: a randomized controlled trial | Clinical otolaryngology and allied sciences | Per ear assignment
21072756 | Paul Hong and Neil Smith and Liane B Johnson and Gerard Corsten | A randomized double-blind controlled trial of phosphorylcholine-coated tympanostomy tube versus standard tympanostomy tube in children with recurrent acute and chronic otitis media | The Laryngoscope | Per ear assignment
2872514 | A R Maw and F Herod | Otoscopic, impedance, and audiometric findings in glue ear treated by adenoidectomy and tonsillectomy. A prospective randomised study | Lancet (London, England) | Per ear assignment
2196954 | N A Black and C F Sanderson and A P Freeland and M P Vessey | A randomised controlled trial of surgery for glue ear | BMJ (Clinical research ed.) | Per ear assignment
1919311 | A R Maw | Development of tympanosclerosis in children with otitis media with effusion and ventilation tubes | The Journal of laryngology and otology | Per ear assignment
650647 | M J Brown and S H Richards and A G Ambegaokar | Grommets and glue ear: a five-year follow up of a controlled trial | Journal of the Royal Society of Medicine | Per ear assignment
3348665 | H R Grant and R E Quiney and D M Mercer and S Lodge | Cleft palate and glue ear | Archives of disease in childhood | Per ear assignment
3243009 | D W Skinner and T H Lesser and S H Richards | A 15 year follow-up of a controlled trial of the use of grommets in glue ear | Clinical otolaryngology and allied sciences | Per ear assignment
16368152 | Uneri C. and Baglam T. and Yazici M. | The effect of Vitamin E treatment on the development of myringosclerosis after ventilation tube insertion | International Journal of Pediatric Otorhinolaryngology (2006) 70:6 (1045–1048). Date of Publication: June 2006 | Per ear assignment
10912691 | Banerjee A.R. and Marshall J.N. and Jennings C. and Narula A.A. | The effect of topical adrenaline on the development of myringosclerosis after tympanostomy tube insertion | American Journal of Otology (2000) 21:4 (482–484). Date of Publication: July 2000 | Per ear assignment
4925501 | Richards S.H. | Grommets and glue ears: A clinical trial | J.Laryng (1971) 85:1 (155–156). Date of Publication: 1971 | Per ear assignment
| Coates H. and Chai F. and Oates J. | The use of surface treated and silver oxide impregnated tympanostomy tubes in reducing postoperative otorrhoea | Australian Journal of Otolaryngology (1998) 3:1 (16–19). Date of Publication: Jan 1998 | Per ear assignment
27063749 | Han Zhang and Yaser Alrajhi and Hamdy El-Hakim | Variables associated with repeated ventilation tube insertion in healthy non- syndromic children | May | Retrospective cohort N < 1000
456299 | M Kremer and L Podoshin and M Fradis | Treatment of serous otitis media with tympanic ventilation tubes | Ear, nose, & throat journal | Retrospective cohort N < 1000
16214225 | Ingrid Augustsson and Ingemar Engstrand | Hearing loss as a sequel of secretory and acute otitis media as reflected by audiometric screening of Swedish conscripts | International journal of pediatric otorhinolaryngology | Retrospective cohort N < 1000
2845850 | M François and O Laccourreye and J N Margo and V Herman and P Narcy | [Short-term complications of transtympanic aerators] | Annales d’oto-laryngologie et de chirurgie cervico faciale: bulletin de la Société d’otolaryngologie des hôpitaux de Paris | Retrospective cohort N < 1000
8470547 | E Manders and J Tyberghein | The effects of ventilation tube placement on hearing, speech, language, cognition and behaviour | Acta oto-rhino-laryngologica Belgica | Retrospective cohort N < 1000
| Walker P. | Persistent perforation following spontaneous extrusion of ventilation tubes in children | Australian Journal of Otolaryngology (2003) 6:1 (18–23). Date of Publication: May 2003 | Retrospective cohort N < 1000
| Somekawa Y. | Ear discharge following insertion of tympanostomy tube | Oto-Rhino-Laryngology Tokyo (1981) 24:6 (23–31+3). Date of Publication: 1981 | Retrospective cohort N < 1000
26443477 | Richard M Rosenfeld and Krishna Sury and Christopher Mascarinas | Office Insertion of Tympanostomy Tubes without Anesthesia in Young Children | Dec | Retrospective cohort N < 1000
12567079 | Ron B Mitchell and Ellen Call and James Kelly | Ear, nose and throat disorders in children with Down syndrome | The Laryngoscope | Retrospective cohort N < 1000
1451676 | S S Hussain | Extrusion rate of Shah and Shepard ventilation tubes in children | Ear, nose, & throat journal | Retrospective cohort N < 1000
16822553 | Fatma Homood Al Anazy | Iatrogenic cholesteatoma in children with OME in a training program | International journal of pediatric otorhinolaryngology | Retrospective cohort N < 1000
12707661 | M Tayyar Kalcioglu and Yasar Cokkeser and Ahmet Kizilay and Orhan Ozturan | Follow-up of 366 ears after tympanostomy tube insertion: why is it draining? | Otolaryngology--head and neck surgery: official journal of American Academy of Otolaryngology-Head and Neck Surgery | Retrospective cohort N < 1000
17970145 | Svetlana Diacova and Thomas J McDonald | A comparison of outcomes following tympanostomy tube placement or conservative measures for management of otitis media with effusion | Ear, nose, & throat journal | Retrospective cohort N < 1000
15373873 | D S Kim and P L A Moore and T J Rockley | Long-term Paparella II grommet use in the management of persistent childhood otitis media: a 5-year follow-up study | Clinical otolaryngology and allied sciences | Retrospective cohort N < 1000
6890608 | W M Luxford and J L Sheehy | Myringotomy and ventilation tubes: a report of 1,568 ears | The Laryngoscope | Retrospective cohort N < 1000
22518157 | Bilal Gani and A J Kinshuck and R Sharma | A review of hearing loss in cleft palate patients | International journal of otolaryngology | Retrospective cohort N < 1000
7242199 | J H Per-Lee | Long-term middle ear ventilation | The Laryngoscope | Retrospective cohort N < 1000
8436454 | K S Mangat and G A Morrison and T M Ganniwalla | T-tubes: a retrospective review of 1274 insertions over a 4-year period | International journal of pediatric otorhinolaryngology | Retrospective cohort N < 1000
6874239 | J F Sederberg-Olsen and A E Sederberg-Olsen and A M Jensen | The prognostic significance of the air volume in the middle ear for the tendency to recurrence of secretory middle ear condition | International journal of pediatric otorhinolaryngology | Retrospective cohort N < 1000
3835916 | Y Kawasaki and Y Sakamoto and Y Honmura and T Tatehara and K Miyagawa and Y Urao and J Kanzaki | Long-term results of ventilation tube for otitis media with effusion in children | Auris, nasus, larynx | Retrospective cohort N < 1000
9118577 | D Strachan and G Hope and M Hussain | Long-term follow-up of children inserted with T-tubes as a primary procedure for otitis media with effusion | Clinical otolaryngology and allied sciences | Retrospective cohort N < 1000
4809194 | Paradise J.L. and Bluestone C.D. | Early treatment of the universal otitis media of infants with cleft palate | Pediatrics (1974) 53:1 (48–54). Date of Publication: 1974 | Retrospective cohort N < 1000
| Laurikainen E. and Suonpaa J. | Topical use of aminoglycoside ear drops in children with purulent draining ventilation tubes. A follow-up study | Acta Oto-Laryngologica (1984) 98:SUPPL. 412 (103–104). Date of Publication: 1984 | Retrospective cohort N < 1000
| Kowata I. and Kobayashi S. and Onodera A. | Follow-up study of secretory otitis media in children | Otologia Fukuoka (1979) 25:SUPPL. 1 (153–157). Date of Publication: 1979 | Retrospective cohort N < 1000
| Ichihara T. and Haginomori S.-I. and Mori A. and Kanazawa A. and Nishikado A. and Kawata R. | Ventilation tube treatment in children with otitis media with effusion | Otolaryngology - Head and Neck Surgery (United States) (2012) 147 SUPPL. 2 (P225). Date of Publication: August 2012 | Retrospective cohort N < 1000
| Boedts D. | Middle ear ventilation and tympanic membrane tube (Dutch) | Tijdschrift voor Geneeskunde (1975) 31:8 (395–397). Date of Publication: 1975 | Retrospective cohort N < 1000
| Gristwood R. | Management of the draining ventilation tube in secretory otitis media | Australian Journal of Otolaryngology (1998) 3:2 (147–148). Date of Publication: 1998 | Retrospective cohort N < 1000
| Meghji S. and Rea P. | Follow-up audit for grommets for persistent otitis media with effusion: Are we follow nice guidelines? | International Journal of Surgery (2013) 11:8 (637). Date of Publication: 2013 | Retrospective cohort N < 1000
3955712 | F Odehnal and A Tomecková | [Tympanic ventilation tubes in the so-called “glue ear”] | Ceskoslovenská otolaryngologie | Retrospective cohort N < 1000
4040160 | Y Somekawa and K Kobayashi and T Yamaguchi and K Shimoda and T Suzuki and A Kataura | [Long-term result of grommets in children with secretory otitis media] | Nihon Jibiinkoka Gakkai kaiho | Retrospective cohort N < 1000
12235880 | Hiroshi Ogawa | [Otitis media with effusion: a study of 346 cases in an outpatient clinic] | Nihon Jibiinkoka Gakkai kaiho | Retrospective cohort N < 1000
2594453 | M E Pichichero and L R Berghash and A S Hengerer | Anatomic and audiologic sequelae after tympanostomy tube insertion or prolonged antibiotic therapy for otitis media | The Pediatric infectious disease journal | Retrospective cohort N < 1000
3927225 | M R Klingensmith and M Strauss and G H Conner | A comparison of retention and complication rates of large-bore (Paparella II) and small-bore middle ear ventilating tubes | Otolaryngology--head and neck surgery: official journal of American Academy of Otolaryngology-Head and Neck Surgery | Retrospective cohort N < 1000
16813031 | Stanley Mui and Barry M Rasgon and Raymond L Hilsinger and Brent Lewis and Gretchen Lactao | Tympanostomy tubes for otitis media: quality-of-life improvement for children and parents | Ear, nose, & throat journal | Retrospective cohort N < 1000
5058477 | S R Mawson and P Fagan | Tympanic effusions in children. Long-term results of treatment by myringotomy, aspiration and indwelling tubes (grommets) | The Journal of laryngology and otology | Retrospective cohort N < 1000
4041175 | V Svane-Knudsen and T Lildholdt | Sequelae of ventilation tubes following tonsillectomy | Archives of oto-rhino-laryngology | Retrospective cohort N < 1000
2037413 | B H Matt and R P Miller and R M Meyers and J M Campbell and R T Cotton | Incidence of perforation with Goode T-tube | International journal of pediatric otorhinolaryngology | Retrospective cohort N < 1000
3698323 | J W Curley | Grommet insertion: some basic questions answered | Clinical otolaryngology and allied sciences | Retrospective cohort N < 1000
955999 | A E Kortekangas and E Virolainen | [Experiences with polyethylene ventilation tubes in children with recurrent middle ear inflammation (author’s transl)] | HNO | Retrospective cohort N < 1000
2631910 | M T Dueñas Polo and J L Pardal Refoyo and A Ramos Macías and F Ruiz Martín and A Cañizo Alvarez | [Transtympanic ventilation tubes and serous otitis media. Study of 100 cases] | Acta otorrinolaringológica española | Retrospective cohort N < 1000
1867910 | J Vallés Fontanet and X Perramón Montoliu | [The clinical evolution of transtympanic ventilation tubes in serous otitis. A study of 123 cases] | Acta otorrinolaringológica española | Retrospective cohort N < 1000
6538920 | G Geyer | [The seromucous tympanum] | Laryngologie, Rhinologie, Otologie | Retrospective cohort N < 1000
7873230 | J A Jiménez Antolín and O Lasso Luis and E Muñoz Platón and M Rodríguez Francos and E Galdeano Granda | [Myringotomy and transtympanic ventilation tubes in secretory otitis media. A study of 108 children] | Acta otorrinolaringológica española | Retrospective cohort N < 1000
15583925 | V Gudziol and W J Mann | [Otological findings in adults with isolated cleft palate or cleft lip, jaw, and palate] | Mund-, Kiefer- und Gesichtschirurgie: MKG | Retrospective cohort N < 1000
3618986 | P Canals Ruiz and J L Peris Beaufills and F López Catalá and C Morera Pérez | [Secretory otitis media: surgical treatment and results] | Anales otorrinolaringológicos ibero-americanos | Retrospective cohort N < 1000
8991399 | J L Lacosta and M Zabaleta and I Erdozain | [The evolution of otitis media with effusion treated by transtympanic drainage] | Acta otorrinolaringológica española | Retrospective cohort N < 1000
8928639 | C Stenström and L Ingvarsson | Late effects on ear disease in otitis-prone children: a long-term follow-up study | Acta oto-laryngologica | Retrospective cohort N < 1000
26443477 | Richard M Rosenfeld and Krishna Sury and Christopher Mascarinas | Office Insertion of Tympanostomy Tubes without Anesthesia in Young Children | Otolaryngology--head and neck surgery: official journal of American Academy of Otolaryngology-Head and Neck Surgery | Retrospective cohort N < 1000
5074564 | N Stangeland | [Otosalpingitis--treatment with a polyethylene tube in the ear drum] | Tidsskrift for den Norske lægeforening: tidsskrift for praktisk medicin, ny række | Retrospective cohort N < 1000
7462026 | J E Hug and C R Pfaltz | [Short- or long-term middle ear ventilation? (author’s transl)] | HNO | Retrospective cohort N < 1000
4636406 | C von Sydow | [Middle-ear drainage in otosalpingitis] | Läkartidningen | Retrospective cohort N < 1000
10853347 | M Fücsek and M Gábriel | [Long-term results of tube insertion in treating otitis media with effusion] | Orvosi hetilap | Retrospective cohort N < 1000
3604104 | K Haralampiev and B Kitanoski and B Ristić and M Jaćimović | [Surgical treatment of chronic secretory otitis using aeration-drainage tubes] | Vojnosanitetski pregled | Retrospective cohort N < 1000
7569388 | J P Dachy and I Evrard | | Revue de laryngologie - otologie - rhinologie | Retrospective cohort N < 1000
8191069 | F Devars and L Traissac | [Goode’s transtympanic drains. Indications and complications] | Revue de laryngologie - otologie - rhinologie | Retrospective cohort N < 1000
16903334 | Beata Zielnik-Jurkiewicz and Olga Olszewska-Sosińska and Magdalena Rakowska | [Results of treatment with tympanostomy tubes in children with otitis media with effusion] | Otolaryngologia polska = The Polish otolaryngology | Retrospective cohort N < 1000
9518333 | B Zielnik-Jurkiewicz and J Gutkowska | [Effect of surgical treatment of otitis media with effusion on children. Personal experience] | Otolaryngologia polska = The Polish otolaryngology | Retrospective cohort N < 1000
156771 | M Wayoff and J P Kocher and C Chobaut and C Simon | [Long-term results of transtympanic drainage] | Journal français d’oto-rhino-laryngologie; audiophonologie, chirurgie maxillo-faciale | Retrospective cohort N < 1000
4039907 | M Klein | [Presentation and trial of a new medium- duration transtympanic ventilator] | Annales d’oto-laryngologie et de chirurgie cervico faciale: bulletin de la Société d’oto-laryngologie des hôpitaux de Paris | Retrospective cohort N < 1000
3705232 | J F Sederberg-Olsen and A E Sederberg-Olsen and A M Jensen | [Complications of grommets in specialist practice] | Ugeskrift for laeger | Retrospective cohort N < 1000
10337163 | S Chodynicki and B Lazarczyk | [The results of treatment of otitis media with suppuration in children by ventilation tubes] | Otolaryngologia polska = The Polish otolaryngology | Retrospective cohort N < 1000
25554572 | Axel Håkansson and Rut Florentzson and Lisa Tuomi and Caterina Finizia | Transmyringeal ventilation tube treatment in children: hearing outcome after 10 years | International journal of pediatric otorhinolaryngology | Retrospective cohort N < 1000
21846926 | Inessa Fishman and Kevin J Sykes and Rebecca Horvat and Rangaraj Selvarangan and Jason Newland and Julie L Wei | Demographics and microbiology of otorrhea through patent tubes failing ototopical and/or oral antibiotic therapy | Otolaryngology--head and neck surgery: official journal of American Academy of Otolaryngology-Head and Neck Surgery | Retrospective cohort N < 1000
9119591 | T Saito and E Iwaki and Y Kohno and T Ohtsubo and I Noda and S Mori and T Yamamoto and Y Shibamori and H Saito | Prevention of persistent ear drum perforation after long-term ventilation tube treatment for otitis media with effusion in children | International journal of pediatric otorhinolaryngology | Retrospective cohort N < 1000
16500457 | Frank Hill | The Triune, a new silicone tympanostomy tube | Otolaryngology--head and neck surgery: official journal of American Academy of Otolaryngology-Head and Neck Surgery | Retrospective cohort N < 1000
16230588 | James M Coticchia and Joseph E Dohar | Methicillin-resistant Staphylococcus aureus otorrhea after tympanostomy tube placement | Archives of otolaryngology--head & neck surgery | Retrospective cohort N < 1000
3835921 | N Yanagihara and T Yagi | Limitation of long term ventilation tube: in view of complications and hearing restoration | Auris, nasus, larynx | Retrospective cohort N < 1000
26115935 | Mallory B O’Niel and Laura D Cassidy and T Roxanne Link and Joseph E Kerschner | Tracking tympanostomy tube outcomes in pediatric patients with otitis media using an electronic database | International journal of pediatric otorhinolaryngology | Retrospective cohort N < 1000
3835931 | M Sakai and A Shinkawa and S Saito and H Miyake | Late results of hearing in children treated with tympanostomy tube | Auris, nasus, larynx | Retrospective cohort N < 1000
4843116 | L A Hughes and F R Warder and W R Hudson | Complications of tympanostomy tubes | Archives of otolaryngology (Chicago, Ill.: 1960) | Retrospective cohort N < 1000
11564294 | Y Talmon and H Gadban and A Samet and P Gilbey and V Letichevsky | Medium-term middle ear ventilation with self-manufactured polyethylene T-tubes for the treatment of children with middle ear effusion | The Journal of laryngology and otology | Retrospective cohort N < 1000
9853658 | E Iwaki and T Saito and G Tsuda and C Sugimoto and Y Kimura and N Takahashi and K Fujita and H | Timing for removal of tympanic ventilation tube in children | Auris, nasus, larynx | Retrospective cohort N < 1000
6685748 | Sunaga and H Saito M Ben-Ami and G Rosen and T Shlezinger and S Konack and M Ben-Ami | Otitis media with effusion--complications after treatment | The Journal of laryngology and otology | Retrospective cohort N < 1000
6778333 | W Draf and P Schulz | Insertion of ventilation tubes into the medical ear: results and complications. A seven-year review | The Annals of otology, rhinology & laryngology. Supplement | Retrospective cohort N < 1000
7192378 | J J Holt and S G Harner | Effects of large-bore middle ear ventilation tubes | Otolaryngology and head and neck surgery | Retrospective cohort N < 1000
11738691 | Oren Friedman and Ellen S Deutsch and James S Reilly and Steven P Cook | The feasibility of office-based laser-assisted tympanic membrane fenestration with tympanostomy tube insertion: the duPont Hospital experience | International journal of pediatric otorhinolaryngology | Retrospective cohort N < 1000
8588632 | A G Schilder and G A Zielhuis and M P Haggard and P van den Broek | Long-term effects of otitis media with effusion: otomicroscopic findings | The American journal of otology | Retrospective cohort N < 1000
3915206 | T J Balkany and I K Arenberg and R L Steenerson | Middle ear irrigation during insertion of ventilation tubes | Auris, nasus, larynx | Retrospective cohort N < 1000
15829063 | Marie Ryding and Peter White and Olof Kalm | Course and long-term outcome of ‘refractory’ secretory otitis media | The Journal of laryngology and otology | Retrospective cohort N < 1000
12472518 | P Sheahan and A W Blayney and J N Sheahan and M J Earley | Sequelae of otitis media with effusion among children with cleft lip and/or cleft palate | Clinical otolaryngology and allied sciences | Retrospective cohort N < 1000
26043589 | Vladimir Djordjević and Bojana Bukurov and Nenad Arsović and Snežana Ješić and Jovica Milovanović and Vladimir Nešić | Long term complications of ventilation tube insertion in children with otitis media with effusion | Vojnosanitetski pregled | Retrospective cohort N < 1000
3835919 | M Suzuki and K Kodera | Long term follow-up of secretory otitis media in children: the effects of adenotonsillectomy with insertion of a ventilation tube | Auris, nasus, larynx | Retrospective cohort N < 1000
3189124 | L A Hughes and D Wight | Tympanostomy tubes: long-term effects | American family physician | Retrospective cohort N < 1000
969088 | D G Pappas | Triflanged tube for chronic serous otitis media | Transactions. Section on Otolaryngology. American Academy of Ophthalmology and Otolaryngology | Retrospective cohort N < 1000
18225626 | Arthur H Allen | Is i.v. access necessary for myringotomy with tubes? | Ear, nose, & throat journal | Retrospective cohort N < 1000
3427799 | R W Slack and J M Gardner and C Chatfield | Otorrhoea in children with middle ear ventilation tubes: a comparison of different types of tubes | Clinical otolaryngology and allied sciences | Retrospective cohort N < 1000
6085804 | P Arcand and P Gauthier and G Bilodeau and G Chapados and A Abela and R Desjardins and P P Gagnon and A J Guerguerian | Post-myringotomy care: a prospective study | The Journal of otolaryngology | Retrospective cohort N < 1000
1011326 | T Palva and E Kokko | Middle ear effusions -- complications of disease and treatment | The Journal of otolaryngology | Retrospective cohort N < 1000
10994430 | G D Smyth and C C Patterson and S Hall | Tympanostomy tubes: do they significantly benefit the patient? | Otolaryngology--head and neck surgery: official journal of American Academy of Otolaryngology-Head and Neck Surgery | Retrospective cohort N < 1000
2589073 | J F Sederberg-Olsen and A E Sederberg-Olsen and A M Jensen | Late results of treatment with ventilation tubes for secretory otitis media in ENT practice | Acta oto-laryngologica | Retrospective cohort N < 1000
24735607 | Hye Ran Hong and Tae Su Kim and Jong Woo Chung | Long-term follow-up of otitis media with effusion in children: comparisons between a ventilation tube group and a non-ventilation tube group | International journal of pediatric otorhinolaryngology | Retrospective cohort N < 1000
6682411 | G Pestalozza and G Cusmano and E Tessitore and A Bonelli | Transtympanic drains in the treatment of serous otitis in children; anatomical versus functional long term results | International journal of pediatric otorhinolaryngology | Retrospective cohort N < 1000
20359098 | Qi Gui and Zhinan Wang and Ping Chen | [Retaining time of tympanic ventilation tube and aural complications] | Lin chuang er bi yan hou tou jing wai ke za zhi = Journal of clinical otorhinolaryngology, head, and neck surgery | Retrospective cohort N < 1000
23002647 | Ningbo Wang and Enqin Zhang and Chunbo Lan and Wenwen Xiao and Jiabin Liu | [Clinical research of T tube implantation on children with chronic otitis media] | Lin chuang er bi yan hou tou jing wai ke za zhi = Journal of clinical otorhinolaryngology, head, and neck surgery | Retrospective cohort N < 1000
1874637 | J Mertens and B Schwenk | [Cholesteatoma and chronic tubal middle ear infection in children. A 10 year overview] | HNO | Retrospective cohort N < 1000
26281253 | Sen Li and Hong Zhang and Yun Wei and Xilei Zhang and Yingru Wu and Jiang Qian and Liang Shen and Zhengjian Zhang | [Clinical comparative study on the treatment characteristics of secretory otitis media between cleft and non-cleft palate patients] | Jun | Retrospective cohort N < 1000
9055175 | Hui Y. and Park A. and Crysdale W.S. and Forte V. | Ototoxicity from ototopical aminoglycosides | Journal of Otolaryngology (1997) 26:1 (53–56). Date of Publication: February 1997 | Retrospective cohort N < 1000
6821430 | Leopold D.A. and McCabe B.F. | Factors influencing tympanostomy tube function and extrusion: A study of 1,127 ears | Otolaryngology - Head and Neck Surgery (1980) 88:4 (447–454). Date of Publication: 1980 | Retrospective cohort N < 1000
26548470 | Gabriella Fekete-Szabó and Fekete Kiss and László Rovó | [Long-term follow-up after tympanostomy tube insertion in children with serous otitis media] | Nov | Retrospective cohort N < 1000
27067029 | Chii-Yuan Huang and Chuan-Song Wu and Chao-Hsiun Tang and Mao-Che Wang and Ting-Yu Kuo and Tzong-Yang Tu | Palatoplasty decreases the re-insertion rate of middle ear ventilation tube in cleft palate children - A population-based birth cohort study | Apr | Retrospective cohort N < 1000
6542693 | M Lucić | [Therapy of exudative chronic otitis using ventilating tubes. Results and consequences] | Srpski arhiv za celokupno lekarstvo | Reviewed in abstract only
10377838 | S Sanković and R Dergenc | [Surgical treatment of secretory otitis media: persistent perforation as a rare complication] | Srpski arhiv za celokupno lekarstvo | Reviewed in abstract only
22433702 | | [First experience with the use of tympanostomy for the management of acute otitis media in children] | Vestnik otorinolaringologii | Reviewed in abstract only
21166142 | Elzbieta Hassmann-Poznańska and Artur Goździewski and Małgorzata Piszcz and Hanna Zajaczkiewicz and Bozena Skotnicka | [Influence of tympanic membrane changes on immittance and extended frequency audiometric findings] | Otolaryngologia polska = The Polish otolaryngology | Reviewed in abstract only
7725152 | B Ristić and K Haralampiev and R Filipovski | [Complications in secretory otitis media treated with aeration-drainage tubes] | Srpski arhiv za celokupno lekarstvo | Reviewed in abstract only
| Viada J. and Carcamo F. and Carrillo L. | Evaluation of results with middle ear ventilation tubes in treatment of serous otitis | Revista de Otorrinolaringologia y Cirurgia de Cabeza y Cuello (1979) 39:2 (47–55). Date of Publication: 1979 | Reviewed in abstract only
| Sanchez T.G. and Ognibene R.Z. and Gondin M. and Bento R.F. | Audiometric findings after ear ventilation tubes extrusion | Revista Brasileira de Otorrinolaringologia (1992) 58:2 (99–102). Date of Publication: 1992 | Reviewed in abstract only
| Scherer H. | Transtympanic ventilation of the middle ear by means of tympanic drainage | Praxis Magazin Med. (1995):3 (44+46). Date of Publication: 1995 | Reviewed in abstract only
| Suzuki M. | A long-term follow-up of secretory otitis media in children | Otolaryngology (1984) 56:7 (469–473). Date of Publication: 1984 | Reviewed in abstract only
| Neubauer R. and Slama K. | Experience with the use of a ventilation tube STIPULA in the treatment of otitis media chronica secretoria at the ENT department of the masaryk hospital in Usti nad Labem during a 17-year period | Otorinolaryngologie a Foniatrie (2003) 52:2 (65–70). Date of Publication: 2003 | Reviewed in abstract only
| Ohnishi T. | Comparative study of middle ear ventilating tubes | Otolaryngology (1980) 52:8 (575–581). Date of Publication: 1980 | Reviewed in abstract only
| Paquelin F. and Doncieux D. and Luboinski B. and Henin J.M. | Continuous transtympanic drainage in children with a non purulent cryptogenetic exudate of the middle ear | ANN.OTO-LARYNG. (1973) 90:9 (565–569). Date of Publication: 1973 | Reviewed in abstract only
| Yokoyama T. | Results of tympanostomy tube for children with secretory otitis media | Otolaryngology (1979) 51:9 (655–660). Date of Publication: 1979 | Reviewed in abstract only
| Prauzinska M. and Sroczynski J. and Pucher B. and Szydlowski J. | The effectiveness of ventilation tubes treatment in otitis media with effusion in children | Family Medicine and Primary Care Review (2014) 16:3 (277–278). Date of Publication: July-September 2014 | Reviewed in abstract only
| Rashid D. and Ahmad B. and Malik S.M. and Rahat Z.M. and Malik K.Z. | Otitis media with effusion-cost effective options | Journal of the College of Physicians and Surgeons Pakistan (2002) 12:5 (274–276). Date of Publication: 2002 | Reviewed in abstract only
| Attallah M.S. and Essa A.E. | Common complications following ventilation tube insertion | Indian Journal of Otology (1999) 5:1 (17–20). Date of Publication: 1999 | Reviewed in abstract only
| Yagi T. | The long-term result of middle far ventilation tube | Otolaryngology (1985) 57:6 (463–468). Date of Publication: 1985 | Reviewed in abstract only
| Bartonkova K. and Janecek D. and Lenert R. | Mean time of insertion of a pressure equalizing tube (PET) | Otorinolaryngologie a Foniatrie (2002) 51:3 (161–164). Date of Publication: 2002 | Reviewed in abstract only
| Slapak I. and Hornik P. and Machac J. and Machalova M. and Fryckova A. and Chrobok V. and Vokurka J. and Hybasek I. | Use of a ventilation tube and recurrent otitis media in child age | Otorinolaryngologie a Foniatrie (1999) 48:3 (143–146). Date of Publication: 1999 | Reviewed in abstract only
| Hatanaka E. | Results of treatment with large ventilating tubes and grommet tubes in children with middle ear effusion | Otolaryngology (1983) 55:11 (915–919). Date of Publication: 1983 | Reviewed in abstract only
| Pospiech L. and Rak J. and Jaworska M. and Klempous J. | Effects of surgical and pharmacological management of otitis media with effusion in children admitted to the Otolaryngology Department of the Medical University of Wroclaw | Przeglad Pediatryczny (2001) 31:3 (215–218). Date of Publication: 2001 | Reviewed in abstract only
20873100 | Elzbieta Hassmann-Poznańska and Artur Goździewski and Małgorzata Piszcz and Bozena Skotnicka | [Long term sequelae of otitis media with effusion during childhood] | Otolaryngologia polska = The Polish otolaryngology | Reviewed in abstract only
26860606 | Yakup Yegin and Mustafa Çelik and Burak Olgun and Hasan Emre Koçak and Fatma Tülin Kayhan | Is ventilation tube insertion necessary in children with otitis media with effusion? | Dec | Reviewed in abstract only
26752135 | Kate J Fitzsimons and Lynn P Copley and Jan H {van der Meulen} and Channa Panagamuwa and Scott A Deacon | Grommet Surgery in Children With Orofacial Clefts in England | Jan | Reviewed in abstract only