# Appendix A Literature Search

## MEDLINE (5/19/16, 6553 Citations)

((otitis) OR (“glue ear”) OR “Otitis Media with Effusion”[Mesh] OR “Otitis Media, Suppurative”[Mesh] OR “Ear, Middle/secretion”[Mesh] OR (middle and ear and (effusion* or infect* or inflame* or disease*)) OR ((OME OR SOM or AOM) AND (otitis OR ear)) OR ((mucoid* AND middle AND ear) OR (mucous AND middle AND ear) OR (seromuc* AND middle AND ear)))

AND

(tympanostomy OR grommet* OR ((ear or “pressure equalization” or PE or myringotomy or ventilating or ventilation) and (tube or tubes)) OR “Otitis Media with Effusion/surgery”[mesh] OR “Middle Ear Ventilation”[Mesh] OR ((middle AND (ear OR tympanic)) AND (tube or tubes)) OR “Otologic Surgical Procedures”[Mesh] OR T-tube or tabulation)

## COCHRANE (5/19/16, 393 Citations)

((otitis) OR (“glue ear”) OR [mh “Otitis Media with Effusion”] OR [mh “Otitis Media, Suppurative”] OR [mh “Ear, Middle/secretion”] OR (middle and ear and (effusion* or infect* or inflame* or disease*)) OR ((OME OR SOM or AOM) AND (otitis OR ear)) OR ((mucoid* AND middle AND ear) OR (mucous AND middle AND ear) OR (seromuc* AND middle AND ear)))

AND

(tympanostomy OR grommet* OR ((ear or “pressure equalization” or PE or myringotomy or ventilating or ventilation) and (tube or tubes)) OR [mh “Otitis Media with Effusion/surgery”] OR [mh “Middle Ear Ventilation”] OR ((middle AND (ear OR tympanic)) AND (tube or tubes)) OR [mh “Otologic Surgical Procedures”] OR T-tube or tabulation)

## CINAHL (5/19/16, 852 Citations)

((MH “Otitis”) OR (MH “Otitis Media with Effusion”) OR (MH “Otitis Media”) OR otitis OR (“glue ear”) OR (MH “Ear, Middle”) OR (middle and ear and (effusion* or infect* or inflame* or disease*)) OR ((OME OR SOM or AOM) AND (otitis OR ear)) OR ((mucoid* AND middle AND ear) OR (mucous AND middle AND ear) OR (seromuc* AND middle AND ear)))

AND

(tympanostomy or myringotomy OR (MH “Middle Ear Ventilation”) OR grommet* OR ((ear or “pressure equalization” or PE or myringotomy or ventilating or ventilation) and (tube or tubes)) OR ((middle AND (ear OR tympanic)) AND (tube or tubes)) OR (MH “Ear Surgery”) OR T-tube or tabulation)

## EMBASE (5/19/16, 5556 Citations)

(otitis OR ‘otitis media’/exp OR glue ear OR (middle and ear and (effusion* or infect* or inflame* or disease*)) OR ((OME OR SOM or AOM) AND (otitis OR ear)) OR ((mucoid* AND middle AND ear) OR (mucous AND middle AND ear) OR (seromuc* AND middle AND ear)))

AND

(tympanostomy OR ‘tympanostomy tube’/exp OR ‘myringotomy’/exp OR ‘middle ear ventilation’/exp OR grommet* OR ((ear or “pressure equalization” or PE or myringotomy or ventilating or ventilation) and (tube or tubes)) OR ((middle AND (ear OR tympanic)) AND (tube or tubes)) OR T-tube or tabulation)