# Results

This chapter begins with a summary of our literature search and selection. A description of the characteristics and methodological quality of the studies follows. We then present the findings for intermediate and effectiveness outcomes (Key Question [KQ] 1) using separate sections for each condition category. Findings for harms across all conditions (KQ2) follow. Within each section we present a general description of the included studies followed by the findings for the various comparisons examined in the evidence base. Metagraphs and tables reporting the strength of evidence (SOE) for key outcomes are available within each applicable section. As per our methods, precision in effect estimates from meta-analyses (pair-wise and network) is reported using credible intervals (95% CrI), while that from single study results is indicated by a confidence interval (95% CI). Moreover, the wording used when interpreting findings is standardized with “will”, “probably/likely”, “may/appears to”, and “not known” for cases of high, moderate, low, and insufficient SOE, respectively; the magnitude of effects are stated as “increase/improve/decrease/worsen” (as suitable) or “increase/improve/decrease/worsen slightly/to a small extent”, for effects that are probably clinically important for at least some patients or small, respectively. When there appears to be no difference in effect, we use “makes little or no difference”. Throughout this report, a “significant” result refers to a finding that is statistically significant. We do not infer that statistically significant results are necessarily clinically meaningful.

Several appendixes provide supporting information to the findings presented in this section. Appendix C provides the quality assessment ratings by domain for each study. Appendix D contains detailed evidence tables describing the study, participant, and treatment characteristics, outcomes for each study. A table citing all associated publications is included in Appendix E, and a list of citations for the excluded and unobtained studies is available in Appendix F. Appendix G contains findings for our network meta-analysis and general adverse effects (AEs) that are not included in the main body of the report.

## Literature Search and Screening

Our database searches identified 12,677 citations, and 11 additional records were identified from other sources including reference lists of systematic reviews and included studies, handsearching of journal websites, and our search of regulatory documents. In total, we included 57 new studies in addition to 78 from the original comparative effectiveness review (CER) (N = 135). Three previously included studies were excluded; two were reported in insufficient formats (e.g., abstract)^62, 63^ and another had a large proportion of drugs within its first-generation antipsychotic (FGA) group not currently approved by the FDA.^64^ We included several studies published during the timeframe of the original CER, largely reflecting our inclusion of pooled analyses of trial data and the expanded number of conditions of interest; some observational studies were previously excluded because of a relatively high proportion of patients having conditions within our newly included categories of depression, anxiety, and substance use disorders. Figure 2 describes the flow of literature through the screening process and the number of studies included by condition. Appendix F provides a complete list of articles excluded at the full-text screening stage, with reasons for exclusion.

Figure 2 Flow of literature through study search and selection process

ADHD = attention deficit hyperactivity disorder

^a^One study provided separate data for both bipolar disorder and schizophrenia;

^b^Studies with populations having multiple primary diagnosis were included for key question 2 on harms only.

Figure 2 is a flow chart that summarizes the search and selection of articles. It begins with the total number of citations retrieved from electronic literature searches and originally included studies, and ends with the number of unique studies that satisfied the inclusion criteria of the report. Electronic searches identified 12,677 citations which were added to the 140 original included studies. 12,020 studies were excluded after screening titles and abstracts, leaving 797 potentially relevant articles to be retrieved and evaluated for inclusion. 11 additional citations were included from other sources, including reference lists of systematic reviews and included studies. In total 808 full-text articles were screened for inclusion, 217 were included and 591 were excluded. There were 135 unique studies and 82 associated publications for the following conditions: schizophrenia and related disorders (39), autism spectrum disorder (23), bipolar disorder (19), ADHD and disruptive, impulse-control, and conduct disorders (13), obsessive compulsive disorder (1), depression (1), eating disorders (3), tic disorders (12), behavioral issues (2), and multiple conditions (23). Studies with populations having multiple primary diagnoses were included for KQ2 on harms only. Reasons for exclusion were: age (240), not primary research (56), study design (77), intervention (50), outcome (23), diagnosis (9), language (3), duplicate (6) and unable to retrieve (1).

## Description of Included Studies

A total of 135 unique studies met the eligibility criteria for this review. Evidence tables in Appendix D describe the characteristics of the studies. The studies were published between 1989 and 2016 (median = 2008 [interquartile range (IQR), 2004 to 2012]). Most of the studies (98%) were reported in peer-reviewed publications. Studies were conducted in the United States (52%), Europe (16%), Israel (3%), Canada (4%), other regions (13%), or in multiple countries (12%).

A total of 100 studies (74%) examined antipsychotics for intermediate and effectiveness outcomes (KQ 1). Harms (KQ 2) were reported in 126 studies (93%). Of the 135 studies, 89 (66%) were randomized controlled trials (RCTs) and 6 were nonrandomized controlled trials (NRCTs) (4%). Most of the trials had a parallel design and two treatment arms. Eight trials used a crossover design; 20 trials had three or four arms. A total of 40 observational studies were included.

The studies examined the following conditions: schizophrenia or schizophrenia-related psychosis (39 studies); autism spectrum disorders (ASD) (23 studies); bipolar disorder (19 studies); attention deficit hyperactivity disorder (ADHD) or disruptive, impulse control, or conduct disorders (DICD; 13 studies); obsessive-compulsive disorder (OCD) (1 study); depression (1 study); eating disorders (3 studies); tic disorders (12 studies); behavioral issues outside the context of a disorder (2 studies); and patients diagnosed with various psychiatric and behavioral conditions (“mixed conditions” contributing to harms data only; 23 studies). One study provided separate data for both pediatric bipolar disorder and schizophrenia.^65^ Another study of first-episode psychotic mania included a mixed sample of patients initially diagnosed with bipolar or schizoaffective disorder; because the primary focus was on mania and considering the diagnostic instability in these conditions, clinicians suggested we included this study in the section on bipolar disorders.^66^ None of the included studies exclusively examined anxiety disorders, posttraumatic stress disorder, or substance use disorder.

The number of enrolled/examined participants ranged from 8 to 4140 (median = 60; IQR, 30 to 119). The mean age of study participants ranged from 4 to 22 years (median, 13; IQR, 9.9.8 to 15.35). The mean age was lower than 12 years in 52 studies (39%). One hundred and one (75%) studies reported on followup durations of < 6 months, 10 reported on both short- and long-term followup, and 24 reported only on longer-term followup.

Overall, 113 studies provided one or more head-to-head comparisons of different FGAs or second-generation antipsychotics (SGAs) (Table 2). A total of 21 studies compared different doses of the same antipsychotic, and 56 studies compared one antipsychotic with placebo (risperidone N= 22, aripiprazole N = 10, olanzapine N = 6, quetiapine and ziprasidone N = 4, haloperidol N = 3, others N < 3).

Table 2 Head-to-head comparisons examined in the review

Comparison | Number of Studies | Comparison | Number of Studies
FGAs vs. FGAs | 2 | SGAs vs. SGAs | 84
Haloperidol vs. pimozide | 2 | Aripiprazole vs. olanzapine | 3
| | Aripiprazole vs. paliperidone | 1
FGAs vs. SGAs | 27 | Aripiprazole vs. quetiapine | 3
Chlorpromazine vs olanzapine | 1 | Aripiprazole vs. risperidone | 8
Haloperidol vs. aripiprazole | 1 | Aripiprazole vs. various SGAs | 1
Haloperidol vs. clozapine | 3 | Aripiprazole vs. ziprasidone | 3
Haloperidol vs. olanzapine | 8 | Clozapine vs. olanzapine | 7
Haloperidol vs. risperidone | 5 | Clozapine vs. quetiapine | 1
Molindone vs. olanzapine | 1 | Clozapine vs. risperidone | 3
Molindone vs. risperidone | 1 | Olanzapine vs. quetiapine | 11
Pimozide vs. aripiprazole | 2 | Olanzapine vs. risperidone | 22
Pimozide vs. risperidone | 2 | Olanzapine vs. ziprasidone | 3
Various FGAs vs. various SGAs | 3 | Quetiapine vs. risperidone | 13
| | Quetiapine vs. ziprasidone | 2
| | Risperidone vs various SGAs | 2
| | Risperidone vs. ziprasidone | 1

FGA = first-generation antipsychotic; SGA = second-generation antipsychotic

## Methodological Quality of Included Studies

The methodological quality of each study was assessed by two independent reviewers and consensus was reached for final assessments. Figures 3 and 4 contain a summary of the quality assessments for trials and observational studies, respectively. The consensus ratings for each study and domain are presented in Appendix C, Tables C1 and C2.

Figure 3 Risk of bias summary for trials of first- and second-generation antipsychotics in children and young adults

n = number of studies

Figure 3 displays Risk of Bias summary chart for trials of FGAs and SGAs in children and young adults. This figure is described further in the section “Methodological Quality of Included Studies” as follows: “the consensus ratings for each study and domain are presented in Appendix C, Tables C1 and C2. For subjective outcomes in trials, the overall ROB was rated as high for 60 percent; only eight were assessed as low ROB. The ROB reduced to a small extent for objective outcomes. The main contributor to ROB was incomplete outcome data, which has rated as high ROB when drop-out/incompletion rates were ≥ 30 percent, or when differences between study groups in numbers and reasons for withdrawal were considered substantial.”

Figure 4 Summary of ratings of methodological quality for observational studies of first- and second-generation antipsychotics in children and young adults

n = number of studies

^a^The question on comparability of cohorts is the only one that has a possible score of 2 stars.

Figure 4 shows a summary of ratings of methodological quality for observational studies of FGAs and SGAs in children and young adults. This figure is described further in the section “Methodological Quality of Included Studies” as follows: “the consensus ratings for each study and domain and presented in Appendix C, Tables C1 and C2. Overall, the observational studies were of quite high quality; of 39 studies, 4 (10 percent) were rated as having poor quality (3 stars out of 8), 11 (28 percent) as having moderate quality, and 24 (62 percent) as high. Almost half of the studies did not account in some way for variables of confounding considered important (i.e., treatment history, duration/stage of illness).”

For subjective outcomes in trials, the overall ROB was rated as high for 60 percent; only eight were assessed as low ROB. The ROB reduced to a small extent for objective outcomes. The main contributor to ROB was incomplete outcome data, which has rated as high ROB when drop-out/incompletion rates were ≥ 30 percent, or when differences between study groups in numbers and reasons for withdrawal were considered substantial. Overall, the observational studies were of quite high quality; of 40 studies, 4 (10%) were rated as having poor quality/high ROB (3 stars out of 8), 12 (30%) as having moderate quality/medium ROB, and 24 (60%) as high quality/low ROB. Despite this, the observational studies are still considered of poorer quality (i.e., providing less validity) than the RCTs, because of their inability to completely account for confounding by patient characteristics. Almost half of the studies did not account in some way for variables of confounding considered potentially important (i.e., treatment history, duration/stage of illness).

## Key Question 1 Intermediate and Effectiveness Outcomes

This section reviews the evidence of the effect of antipsychotics on intermediate and effectiveness outcomes (KQ 1). For each condition of interest, we describe the studies that provided data for this review and present the results either within figures or narratively. Each section is organized by comparison, with head-to-head data preceding placebo comparisons.

### Schizophrenia and Related Psychoses: Overview

Thirty-nine studies examined patients with schizophrenia and schizophrenia-related psychosis; 30 were trials ^65, 67–95^ and nine were observational studies.^96–104^ Three publications were identified for studies which in the original CER only had unpublished data.^71, 72, 90^ Tables 3 and 4 highlight key characteristics of the trials and observational studies, respectively. The tables include all studies for this condition, even though six studies only reported on harms and not any intermediate outcomes described in this section.^69, 89, 96, 97, 100, 103^ Individual studies are presented in order of drug comparison, with head-to-head evidence preceding placebo comparisons. Several studies included both head-to-head comparisons and a placebo control; these studies are classified under the head-to-head category. Detailed evidence tables are available in Appendix D.

Table 3 Characteristics of trials examining schizophrenia and related psychosis

First Author, Year, Study Design, Duration | Intervention (N Enrolled), Dosage (mg/day) Mean±SD | Age, Mean±SD (Range)/Males (%)/White (%) Comorbidities | Diagnosis Breakdown (n), History of Treatment, Quality Rating
FGAs vs. SGAs
Kumra, 1996^77^ RCT, 6 wk | G1: Haloperidol (11), 16±8 mg/day G2: Clozapine (10), 176±149 mg/day | G1: 13.7±1.6 yr/Male: 55%/White: NR G2: 14.4±2.9 yr/Male: 50%/White: NR Comorbidities: NR | disorganized (10), paranoid (1), undifferentiated (10) History of treatment: 100% resistant to FGAs ROB: High (subjective), High (objective)
de Haan, 2003^70^ RCT, 6 wk | G1: Haloperidol (12), 2.5 mg/day G2: Olanzapine (12), 7.5 mg/day | G1: 21.0±2.8 yr/Male: NR/White: NR G2: 21±2.3 yr/Male: NR/White: NR Comorbidities: NR | disorganized (6), paranoid (13), undifferentiated (5) History of treatment: 0% drug naïve ROB: High (subjective), High (objective)
Buchsbaum, 2007^91^ RCT, 8 wk | G1: Haloperidol (7), up to 20 mg/day G2: Olanzapione (12), up to 20 mg/day | G1: 16.2±2.0yr/Male: 53%/White: NR G2: see group 1 Comorbidities: NR | schizophrenia (14), schizoaffective disorder (2), bipolar affective (4) History of treatment: 100% drug naïve ROB: Medium (subjective), NA (objective)
Sikich, 2004^82^ RCT, 8 wk | G1: Haloperidol (15), 5±2 mg/day G2: Olanzapine (16), 12.3±3.5 mg/day G3: Risperidone (19), 4±1.2 mg/day | G1: 15.4±2.2 yr/Male: 53%/White: 73% G2: 14.6±3.1 yr/Male: 56%/White: 63% G3: 14.6±2.9 yr/Male: 68%/White: 47% Comorbidities: NR | affective disorders (24), schizophrenia spectrum (26) History of treatment: 26% drug naïve ROB: High (subjective), High (objective)
Yen, 2004^87^ RCT, 12 wk | G1: Haloperidol (2), 11.2±6.9 mg/day G2: Risperidone (6), 4.4±2.6 mg/day | G1: 24 yr/Male: 0/White: NR G2: 20.7 yr/Male: 67%/White: NR Comorbidities: NR | schizophrenia (8) History of treatment: 0% drug naïve ROB: High (subjective), High (objective)
Sikich, 2008^81^ RCT, 8 wk (44 wk extension) | G1: Molindone (41), 59.9±33.5 mg/kg G2: Olanzapine (36), 11.4±5 mg/day G3: Risperidone (42), 2.8±1.4 mg/day | G1: NR/Male: 58%/White: 70% G2: NR/Male: 71%/White: 60% G3: NR/Male: 66%/White: 61% Comorbidities: ADHD (22), affective disorder (19), anxiety disorder (21), ASD (5), DBD (16), learning disability (3), psychosis (10), SA (4) | schizoaffective disorder (26), schizophrenia (50) History of treatment: 33% drug naïve ROB: Low (subjective), Low (objective)
SGAs vs. SGAs
Findling, 2015a^92^ RCT, 8 wk | G1: Asenapine (106), 5mg bid G2: Asenapine (98), 2.5mg bid G3: Placebo (102) | G1: 15.4±1.5yr/Male: 63%/White: 52% G2: 15.2±1.5yr/Male: 63%/White: 55% G3: 15.4±1.4yr/Male: 61%/White: 56% Comorbidities: NRI | schizophrenia (306) History of treatment: 32% drug naïve ROB: Low (subjective), Low (objective)
Findling, 2008a^73^ RCT, 6 wk | G1: Aripiprazole (low) (100), 9.8 mg/day G2: Aripiprazole (high) (102), 28.9 mg/day G3: Placebo (100) | G1: 15.6±1.3 yr/Male: 45%/White: 54% G2: 15.4±1.4 yr/Male: 64%/White: 61% G3: 15.4 ±1.4 yr/Male: 61%/White: 64% Comorbidities: NR | schizophrenia (302) History of treatment: 26% drug naïve ROB: Medium (subjective), Medium (objective)
Kumra, 2008^78^ RCT, 12 wk | G1: Clozapine (18), 403.1±201.8 mg/day G2: Olanzapine (21), 26.2±6.5 mg/day | G1: 15.8±2.2 yr/Male: 44%/White: 11% G2: 15.5±2.1 yr/Male: 62%/White: 29% Comorbidities: NR | schizoaffective disorder (14), schizophrenia (25) History of treatment: 100% resistant to ≥2 antipsychotic trials ROB: High (subjective), High (objective)
Shaw, 2006^80^ RCT, 8 wk | G1: Clozapine (12), 327±113 mg/day G2: Olanzapine (13), 18.1±4.3 mg/day | G1: 11.7±2.3 yr/Male: 67%/White: 58% G2: 12.8±2.4 yr/Male: 54%/White: 54% Comorbidities: ADHD/ODD/CD (7), anxiety disorders (7) | Childhood-onset schizophrenia (25) History of treatment: 100% resistant to ≥2 different antipsychotics ROB: Medium (subjective), Medium (objective)
Arango, 2009^67^ RCT, 6 mo | G1: Olanzapine (26), 9.7±6.6 mg/day G2: Quetiapine (24), 532.8±459.6 mg/day | G1: 15.7±1.4 yr/Male: 76%/White: 77% G2: 16.3±1.1 yr/Male: 79%/White: 88% Comorbidities: NR | BD (13), schizophrenia (17), other psychoses (20) History of treatment: 50% drug naïve ROB: High (subjective), High (objective)
Jensen, 2008^75^ RCT, 12 wk | G1: Olanzapine (10), 14±4.6 mg/day G2: Quetiapine (10), 611±253.4 mg/day G3: Risperidone (10), 3.4±1.5 mg/day | G1: 15.3±1.5 yr/Male: 50%/White: 50% G2: 14.8±2.3 yr/Male: 70%/White: 60% G3: 15.6±2.5 yr/Male: 80%/White: 70% Comorbidities: NR | psychotic disorder NOS (9), schizophrenia/schizoaffective disorder (16), schizophreniform disorder (5) History of treatment: 77% drug naïve ROB: High (subjective), High (objective)
Mozes, 2006^79^ RCT, 12 wk | G1: Olanzapine (12), 8.2±4.4 mg/day G2: Risperidone (13), 1.6±1 mg/day | G1: 11.5±1.6 yr/Male: 42%/White: NR G2: 10.7±1.4 yr/Male: 39%/White: NR Comorbidities: ADHD (3), epilepsy (2), familial mediterranean fever (1), neurofibromatosis (1), OCD (3), tic disorder (1) | disorganized schizophrenia (7), paranoid schizophrenia (6), schizophreniform disorder (10), unspecified schizoprehenia (2) History of treatment: 96% drug naïve ROB: High (subjective), High (objective)
van Bruggen, 2003^85^ RCT, olanzapine 9.8 wk, risperidone 6.7 wk | G1: Olanzapine (18), 15.6±4 mg/day G2: Risperidone (26), 4.4±1.5 mg/day | G1: 21±2.8 yr/Male: 72%/White: NR G2: 20.6±3 yr/Male: 85%/White: NR Comorbidities: NR | NR History of treatment: NR ROB: High (subjective), High (objective)
Crocq, 2007^69^ NRCT, 12 wk Harms | G1: Olanzapine (16), 16.6±4.4 mg/day (oral disintegrating) G2: Olanzapine, (10) 18.0±4.2 mg/day (standard oral tablet) G3: Risperidone (26), 2.8±1.2 mg/day | G1: 16.5±1.7 yr/Male: 31.3%/White: 100% G2: 17.0±1.3yr/Male: 60%/White: 100% G3: 15.2±1.4 yr/Male: 57.7%/White: 100% Comorbidities: NR | schizophreniform disorder (52) History of treatment: 75% drug naïve ROB: NA (subjective), High (objective)
Singh, 2011^90^ RCT, 6 wk | G1: Paliperidone ER (low) (54), 1.5 mg/day G2: Paliperidone ER (medium) (48), 3 (<51 kg), 6 (≥51 kg) G3: Paliperidone ER (high) (48), 6 (<51 kg), 12 (≥51 kg G4: Placebo (51) | G1: 15.1±1.5 yr/Male: 56%/White 65% G2: 15.3±1.6yr/Male: 65%/White71% G3: 15.5±1.6 yr/Male: 70%/White 68% G4: 15.7±1.4 yr/Male: 55%/White 69% Comorbidities: BD (0), MDD (0), MR (0), SUD (0), ASD (0), diabetes (0) | paranoid schizophrenia (143), other (58) History of treatment: 10% drug naïve ROB: High (subjective), Medium (objective)
Johnson & Johnson Pharmaceutical Research and Development, 2011^89^ RCT, 1 wk Harms | G1: Paliperidone ER (8), 0.086 mg/kg/day G2: Paliperidone ER (9), 0.129 mg/kg/day G3: Paliperidone ER (8), 0.171 mg/kg/day | All groups: 14.6±2.2yr/Male: 72%/White: 56% Comorbidities: NR | schizophreniform disorder (8), schizoaffective disorder (7), paranoid (6), undifferentiated (3), disorganized (1) History of treatment: NR ROB: High (subjective), High (objective)
Savitz, 2015^94^ RCT, 8 wk (18 wk extension) | G1: Paliperidone ER (112), 6.75±1.8 mg/day G2: Aripiprazole (114), 11.6±3.0 mg/day | G1: 15.2±1.5yr/Male: 65%/White: 75% G2: 15.4±1.5yr/Male: 67%/White: 77% Comorbidities: NR | schizophrenia (226) History of treatment: 10.6% drug naïve ROB: Medium (subjective), Medium (objective)
Berger, 2008^68^ RCT, 4 wk | G1: Quetiapine (low) (69), 200 mg/day G2: Quetiapine (high) (72), 400 mg/day | G1: 19.7±2.6 yr/Male: 71%/White: NR G2: 19±2.9 yr/Male: 64%/White: NR Comorbidities: SA (58) | nonaffective psychosis (95), affective psychosis (31) History of treatment: 33% drug naïve ROB: Low (subjective), Low (objective)
Findling, 2012a^72^ RCT, 6 wk | G1: Quetiapine (low) (73), 400 mg/day G2: Quetiapine (high) (74), 800 mg/day G3: Placebo (75) | G1: 15.5±1.3 yr/Male: 59%/White: 62% G2: 15.5±1.3 yr/Male: 60%/White: 60% G3: 15.3±1.4 yr/Male: 58%/White: 63% Comorbidities: NR | disorganized (16), paranoid (155), residual (1), undifferentiated (48) History of treatment: NR ROB: High (subjective), High (objective)
Swadi, 2010^84^ RCT, 6 wk | G1: Quetiapine (11), 607 mg/day G2: Risperidone (11), 2.9 mg/day | G1: NR/Male: 55%/White: NR G2: NR/Male: 64%/White: NR Comorbidities: NR | first onset psychotic disorder or a mood disorder with psychotic features History of treatment: 100% drug naïve ROB: High (subjective), High (objective)
Haas, 2009a^74^ RCT, 8 wk | G1: Risperidone (low) (132), 0.4 mg/day G2: Risperidone (high) (125), 4 mg/day | G1: 15.6±1.3 yr/Male: 61%/White: 85% G2: 15.7±1.3 yr/Male: 52%/White: 85% Comorbidities: NR | catatonic (7), disorganized (19), paranoid (175), residual (7), undifferentiated (49) History of treatment: NR ROB: High (subjective), High (objective)
Haas, 2009b^88^ RCT, 6 wk | G1: Risperidone, 1–3 mg/day (54) G2: Risperidone, 4–6 mg/day (50) G3: Placebo (54) | G1: 15.7±1.3 yr/Male: 55%/White: 60% G2: 15.6±1.3 yr/Male: 73%/White: 47% G3: 15.5±1.4 yr/Male: 65%/White: 50% Comorbidities: NR | paranoid (110), undifferentiated (33), disorganized (15), catatonic (1), residual (1) History of treatment: NR ROB: High (subjective), High (objective)
DelBello, 2008^65^ RCT, 3 wk | G1: Ziprasidone (low) (8), target: 80 mg/day G2: Ziprasidone (high) (9), target: 160 mg/day | G1: 14.4±2.3 yr/Male: 52%/White: NR G2: 14.7±2.0 yr/Male: 75%/White: NR Comorbidities: NR | bipolar I disorder (46), schizophrenia or schizoaffective disorder (17) History of treatment: 25% drug naïve ROB: High (subjective), High (objective)
FGAs vs. Placebo
Spencer, 1994^83^ RCT (cross-over), 8 wk | G1: Haloperidol (16),^a^ 2 mg/day G2: Placebo (16)^a^ | All groups: NR (5–11 yr)/Male: NR/White: NR Comorbidities: Prior diagnoses: atypical PDD (5), atypical psychosis (3), borderline personality disorder (1), CD (1), pica (1) | schizophrenia History of treatment: NR ROB: Medium (subjective), Medium (objective)
SGAs vs. Placebo
NCT01149655^95^ RCT, 52 wk maintenance study | G1: Aripiprazole (98), 10–30 mg/day G2: Placebo (48) | G1: 15.3±1.3yr/Male: 63.3%/White: NR G2: 15.6±1.1yr/Male: 70.8%/White: NR Comorbidities: NR | schizophrenia (146) History of treatment: 0% drug naïve; 100% stabilized on aripiprazole ROB: High (subjective), High (objective)
McGorry, 2013^93^ RCT, 52 wk | G1: Cognitive therapy and risperidone (43), up to 2mg/day G2: Cognitive therapy and placebo (44) | G1: 17.6±3.0yr/Male: 35%/White: NR G2: 18.0±2.7yr/Male: 39%/White: NR Comorbidities: NR | ultra-high risk (87) History of treatment: 100% drug naïve ROB: High (subjective), High (objective)
Kryzhanovskaya, 2009^76^ RCT, 6 wk | G1: Olanzapine (72), 11.1 mg/day G2: Placebo (35) | G1: 16.1±1.3 yr/Male: 71%/White: 72% G2: 16.3±1.6 yr/Male: 69%/White: 71% Comorbidities: NR | NR History of treatment: 24% drug naïve ROB: High (subjective), High (objective)
Woods, 2003^86^ RCT, 8 wk (12 mo extension) | G1: Olanzapine (31), 8±3.1 mg/day G2: Placebo (29) | G1: 18.2±5.5 yr/Male: 68%/White: 74% G2: 17.2±4 yr/Male: 62%/White: 59% Comorbidities: SA (marijuana (16), other (11)) | prodromal psychosis (60) History of treatment: 90% drug naïve ROB: High (subjective), High (objective)
Findling, 2013a^71^ RCT, 6 wk | G1: Ziprasidone (193), 67.8 mg/day (<45 kg), target 120–160 mg/day (≥45 kg) G2: Placebo (90) | G1: 15.3 yr/Male: 56%/White: 59% G2: 15.4 yr/Male: 69%/White: 67% Comorbidities: NR | schizophrenia (284), paranoid 65% History of treatment: NR ROB: High (subjective), High (objective)

ADHD = attention deficit hyperactivity disorder; ASD = autism spectrum disorder; BD = bipolar disorder; CD = conduct disorder; DBD = disruptive behavior disorder; ER = extended release; G = group; FGA = first-generation antipsychotic; mg = milligram; mo = month; N = number; NOS = not otherwise specified; NR = not reported; OCD = obsessive-compulsive disorder; ODD = oppositional defiant disorder; PDD = pervasive developmental disorder; RCT = randomized controlled trial; ROB = risk of bias; SUD= substance use disorder; SD = standard deviation; SGA = second-generation antipsychotic; wk = week; yr = year

a All patients received each of the treatments in this cross-over study.

Table 4 Characteristics of observational studies examining schizophrenia and related psychosis

First Author, Year, Study Design, Duration | Intervention (N Enrolled), Dosage (mg/day) Mean±SD | Age, Mean±SD (Range)/Males (%)/White (%) Comorbidities | Diagnosis Breakdown (n) Quality Rating
FGAs vs. SGAs
Cianchetti, 2011^102^ Prospective cohort, 3–11 yr | All groups: 47 enrolled at 3 yr; 41 at 5 yr (analysis accounts for medication not subjects) G1: Haloperidol: (29) mean months treatment 9.4±14.3 G2: Risperidone: (33) mean months of treatment 19.6±17.9 G3: Olanzapine: (12) mean months of treatment 11.7±9.2 G4: Clozapine: (28) mean months of treatment 31.5±916.3 | All groups: 15.5 (range 10–17)/Males: 45%/White: 100% Comorbidities: NR | schizophrenia (29), schizoaffective disorder (18) History of treatment: 100% drug naive 5/8 stars
Wudarsky, 1999^100^ Prospective cohort, 6 wk Harms | G1: Haloperidol (15), 15.3±8.2 mg/day G2: Clozapine (22), 325.4±211 mg/day G3: Olanzapine (10), 17.0±3.5 mg/day | G1: 13.7±1.5 yr/Male: 60%/White NR G2: 14.7±2.3 yr/Male: 73%/White: NR G3: 14.2±2.9 yr/Male: 70%/White: NR Comorbidities: NR | childhood-onset schizophrenia (32), psychosis NOS (3) History of treatment: NR 7/8 stars
Gothelf, 2002^96^ Prospective cohort, 4 wk Harms | G1: Haloperidol (10), 6.5±3.5 mg/day G2: Olanzapine (10), 14.0±4.1 mg/day | G1: 17.0±1.6yr/Male: 100%/White NR G2: 17.0±1.6yr/Male: 100%/White: NR Comorbidities: NR | schizophrenia (100) History of treatment: 5% drug naïve ROB: 3/8 stars
Ratzoni, 2002^99^ Prospective cohort, 12 wk | G1: Haloperidol (8), 7.6±4 mg/day G2: Olanzapine (21), 12.7±3.1 mg/day G3: Risperidone (21), 3.2±1.1 mg/day | G1: 17.3±1.3 yr/Male: 63%/White: NR G2: 17±1.6 yr/Male: 67%/White: NR G3: 17.1±2.1 yr/Male: 57%/White: NR Comorbidities: NR | CD (2), schizoaffective disorder (2), schizophrenia (46) History of treatment: 18% drug naïve 3/8 stars
Hrdlicka, 2009^97^ Retrospective cohort, 6 wk Harms | G1: Haloperidol 6.8±1.1, Perphenazine 12±6.9, Sulpiride 450±409.3 mg/day G2: Clozapine 247.5±118, Olanzapine 15±6.1, Risperidone 2.7±1.3, Ziprasidone 80±0 mg/day | G1: 15.8±1.6yr (all)/Male: 48% (all)/White: NR G2: see above Comorbidities: NR | schizophrenia (56), schizoaffective disorder (15), other schizophrenic disorders (38) History of treatment: NR 5/8 stars
SGAs vs. SGAs
Olfson, 2012^104^ Retrospective cohort, 6 mo | G1: Risperidone (805), dose NR G2: Olanzapine (382), dose NR G3: Quetiapine (260), dose NR G4: Aripiprazole (173), dose NR G5: Ziprasidone (125), dose NR | All groups: Age NR (13–17 yr) G1: Males: 62%/White: 38% G2: Males: 69%/White: 38% G3: Males: 52%/White: 42% G4: Males: 55%/White: 42% G5: Males: 57%/White: 44% (White includes American Indians and Pacific Islanders) Comorbidities: DBD (27–35%), SUD (0–4%), MDD (24–32%), anxiety (8–13%), PDD/MR (0–5%) | schizophrenia (850), schizophreniform (170), schizoaffective (680) History of treatment: 100% drug naïve 7/8 stars
O’Donoghue, 2014^103^ Prospective cohort, 31 wk Harms | G1: Olanzapine & quetiapine (16), dose NR G2: Risperidone (20), dose NR | All groups: 15.9±1.2yr/Males: 58%/White: NR Comorbidities: NR | schizophrenia (32), schizoaffective disorder (2), schizophreniform (2) History of treatment: 100% drug naïve 3/8 stars
Castro-Fornieles, 2007^101^ Prospective cohort, 24 mo | G1: Risperidone (31), 2.8±1.2mg/day G2: Quetiapine (15), 626.8±526 mg/day G3: Olanzapine (14), 11.7±7.0 mg/day | G1: 15.1±2.1yr/Male: 68%/White: 86% (all) G2: 16.4±1.1yr/Male: 67%/White: NR G3: 15.7±1.2yr/Male: 71%/White: NR Comorbidities: NR | psychosis NOS (28), schizophrenia (49), MDD with psychotic symptoms (6), BD (manic with psychosis)(14) (All patients in cohort, n=110) History of treatment: 49.1% drug naïve 6/8 stars
Kumra, 1998^98^ Controlled before-after, G1: 6 wk, G2: 8 wk | G1: Clozapine (15), 317±147 mg/day G2: Olanzapine (8), 17.5±2.3 mg/day | G1: 13.6±1.5 yr/Male: 53%/White: NR G2: 15.3±2.3 yr/Male: 50%/White: NR Comorbidities: NR | disorganized (11), paranoid (3), undifferentiated (9) History of treatment: NR 5/8 stars

ADHD = attention deficit hyperactivity disorder; ASD = autism spectrum disorder; BD = bipolar disorder; CD = conduct disorder; DBD = disruptive behavior disorder; ER = extended release; G = group; FGA = first-generation antipsychotic; KQ = key question; MDD = major depressive disorder; mg = milligram; mo = month; MR = mental retardation; N = number; NOS = not otherwise specified; NR = not reported; OCD = obsessive-compulsive disorder; ODD = oppositional defiant disorder; PDD = pervasive developmental disorder; RCT = randomized controlled trial; ROB = risk of bias; SUD= substance use disorder; SD = standard deviation; SGA = second-generation antipsychotic; wk = week; yr = year

The average age of patients across the studies was 15.8 years (range 8.9–22). Sexes were fairly equally represented across the studies (60.1% male). Among the 22 studies that reported race/ethnicity, the majority (average 65.4%) of patients were white, with the exception of one study of African Americans.^78^ Five studies ^67, 68, 84, 101, 103^ examined patients experiencing a first episode of psychosis; five other studies had a large proportion (>75%) of patients having their first episode.^70, 81, 82, 85, 97^ Childhood- or early-onset schizophrenia was examined in eight studies.^77, 79–81, 83, 98, 100, 104^ Two trials only enrolled patients at ultra-high risk (i.e., prodromal phase) for schizophrenia.^86, 93^ Six studies enrolled patients with affective (e.g., presenting within primary diagnosis of bipolar disorder) and nonaffective (i.e., schizophrenia spectrum) psychosis;^67, 68, 82, 84, 91, 101^ one study included patients with bipolar disorder (not specific to the presence of psychosis) or schizophrenia, although reported data separately for those with schizophrenia.^65^ All other patients had a disorder along the schizophrenia spectrum. A large majority of studies excluded patients with substance-induced psychosis and/or mental retardation. Of 24 studies reporting on the proportion of patients who were antipsychotic-treatment naïve, the average percentage of patients who were naïve was 41 (range 0–100); six studies focused on first treatment^84, 86, 91, 93, 103, 104^ (two of which studied the prodrome phase)^86, 93^ and six focused on patients having prior exposure to antipsychotics.^70, 78, 80, 87, 90, 95^

Haloperidol was compared with various SGAs (clozapine, olanzapine, and risperidone) in five RCTs and four observational studies, molindone was compared with olanzapine and risperidone in one RCT, and one observational study compared a mixture of FGAs with SGAs. Eighteen RCTs and four observational studies compared SGAs. Of these, 13 studies compared different SGAs and nine compared two doses of the same SGA. Haloperidol was compared with placebo in one study. SGAs were compared with placebo in 10 studies. Most studies allowed for variable dosing—often adjusted by clinicians based on tolerability and response—although seven used a fixed dose of medication.^68, 70, 76, 88–90, 92^ Studies not examining treatment naïve patients typically reported wash-out periods of between 1–3 weeks; one study was designed as a maintenance study whereby patients stabilized (duration not reported) on 10 to 30 mg/day of aripiprazole were randomized to maintenance on aripiprazole or discontinuation with replacement by placebo for up to 52 weeks.^95^

Most studies had treatment durations between 4 and 12 weeks; nine studies were 6 months or longer,^67, 81, 86, 93–95, 101, 102, 104^ and four of these long-term studies reported both short- and long-term outcomes.^81, 86, 94, 95^ The majority (70%) of the trials had high risk of bias; the most common source of potential bias was incomplete outcome data (i.e., ≥30% withdrawal or significant imbalance between groups for reasons for withdrawal), although several also failed to incorporate blinding of patients or providers. Three trials had low ROB.^68, 81, 92^ Of the nine observational studies, three were in each of the high,^100, 101, 104^ moderate,^97, 98, 102^ and poor^96, 99, 103^ quality categories.

### Schizophrenia and Related Psychoses: Intermediate Outcomes

Twenty-eight studies reported on intermediate outcomes for use of FGAs and SGAs in schizophrenia and related psychosis. A summary of the key findings, and for observations on subgroup effects, by comparison is provided below. Table 5 contains the findings and SOE assessments for the key outcomes assessed as having at least low SOE; the reason for each SOE decision is included in the table footnotes. A detailed analysis for all comparisons follows.

Table 5 Strength of evidence for schizophrenia and related psychosis: Key intermediate outcomes having at least low strength of evidence

Comparison | Outcome (N Studies, N Patients) | Findings,^a^ Studies, Measurement Tool With Range of Values, if Applicable | Strength of Evidence; Conclusions
SGAs vs. FGAs | Negative symptoms (RCTs: 5, 217) | 4 RCTs:^77, 81, 82, 87^ SMD, 0.0; 95% CrI, −0.55 to 0.50 1 RCT:^91^ No difference (p value NR) | Low; may make little or no difference^b^
SGAs vs. FGAs | Positive symptoms (RCTs: 5, 217) | 4 RCTs:^77, 81, 82, 87^ SMD, −0.25; 95% CrI, −0.92 to 0.29 1 RCT:^91^ No difference (p value NR) | Low; may make little or no difference^b^
SGAs vs. FGAs | Response rates (RCTs: 2, 188) | RR, 1.06; 95% CrI, 0.53 to 2.25^81, 82^ | Low; may make little or no difference ^b^
SGAs vs. FGAs | Global impressions of severity using CGI-S^d^ (RCTs: 2, 124) | MD, −0.21; 95% CrI, −1.19 to 0.67^81, 82^ | Low; may make little or no difference ^c^
Olanzapine vs. risperidone | Negative symptoms (RCTs: 5, 198) | 4 RCTs:^79, 81, 82, 85^ SMD, −0.09; 95% CrI, −0.76 to 0.53 1 RCT:^75^ No difference p = 0.19 | Low; may make little or no difference ^b^
Olanzapine vs. risperidone | Positive symptoms (RCTs: 5, 198) | 4 RCTs:^79, 81, 82, 85^ SMD, −0.11; 95% CrI, −0.76 to 0.40 1 RCT:^75^ No difference p = 0.10 | Low; may make little or no difference ^b^
Olanzapine vs. risperidone | Response rates (RCTs: 4, 156) | RR, 1.01; 95% CrI, 0.51 to 1.9^75, 79, 81, 82^ | Low; may make little or no difference ^b^
Olanzapine vs. risperidone | Global impressions of severity using CGI-S (RCTs: 3, 131) | 1 RCT:^82^ MD, 0.30; 95% CI, −0.53 to 1.13 1 RCT:^81^ MD, 0.30; 95% CI, −0.41 to 1.01 1 RCT:^75^ No difference p = 0.33 | Low; may make little or no difference ^c^
Asenapine high vs. low dose | Response rate (RCTs: 1, 204) | 1 RCT:^92^ RR, 1.00; 95% CI, 0.75 to 1.32 | Low; may make little or no difference
Asenapine high vs. low dose | Global impressions of severity using CGI-S (RCTs: 1, 204) | 1 RCT:^92^ MD, 0.20; 95% CI, −0.05 to 0.45 | Low; may make little or no difference
Quetiapine high vs. low dose | Negative symptoms (RCTs: 2, 238) | 1 RCT:^68^ MD, 1.6; 95% CI, −4.79 to 7.99 (SANS; range 0–25) 1 RCT:^72^ MD, 0.14; 95% CI, −1.81 to 2.09 (PANSS; range 7–49) | Low; may make little or no difference ^b^
Quetiapine high vs. low dose | Response rates (RCTs: 2, 273) | 1 RCT:^68^ RR, 0.73; 95% CI, 0.41 to 1.29 1 RCT:^72^ RR, 1.05; 95% CI, 0.69 to 1.60 | Low; may make little or no difference ^b^
Quetiapine high vs. low dose | Global impressions of severity using CGI-S (RCTs: 2, 238) | 1 RCT:^68^MD, 0.00; 95% CI, −0.35 to 0.35 1 RCT:^72^MD, −0.13; 95% CI, −0.47 to 0.21 | Moderate; probably makes little or no difference ^e^
Quetiapine high vs. low dose | Global impressions of functioning (RCTs: 2, 238) | 1 RCT:^68^ MD, −3.5; 95% CI, −8.37 to 1.37 (GAF; range 1–100) 1 RCT:^72^ MD, 1.9; 95% CI, −2.35 to 6.15 (C-GAS; range 1–100) | Moderate; probably makes little or no difference ^e^
SGAs vs. placebo | Negative symptoms (RCTs: 9, 1788) | MD, −1.31; 95% CrI, −2.05 to −0.58 (PANSS Negative; range 7–49)^71–73, 76, 86, 88, 90, 92, 95^ | Moderate; SGAs probably decrease slightly^e^
SGAs vs. placebo | Positive symptoms (RCTs: 9, 1788) | MD, −2.20; 95% CrI, −2.98 to −1.48 (PANSS Positive; range 7–49)^71–73, 76, 86, 88, 90, 92, 95^ | Moderate; SGAs probably decrease slightly^e^
SGAs vs. placebo | Depression symptoms (RCTs: 2, 420) | 1 RCT:^90^ MD, −0.59; 95% CI, −1.46 to 0.28 1 RCT:^72^ MD, −0.59; 95% CI, −1.45 to 0.27 (PANSS Depression) | Low; may make little or no difference ^e^
SGAs vs. placebo | Response rates (RCTs: 5, 993) | RR, 1.52; 95% CrI, 1.15 to 2.02^72, 76, 88, 90, 92^ | Moderate; SGAs probably increase^e^
SGAs vs. placebo | Global impressions of improvement using CGI-I (RCTs: 6, 1202) | MD, −0.54; 95% CrI, −1.07 to −0.14^71–73, 76, 88, 95^ | Moderate; SGAs probably improve slightly^e^
SGAs vs. placebo | Global impressions of severity using CGI-S (RCTs: 9, 1788) | MD, −0.36; 95% CrI, −0.51 to −0.22^71–73, 76, 86, 88, 90, 92, 95^ | Moderate; SGAs probably improve slightly SGAs^e^
SGAs vs. placebo | Global impressions of functioning (RCTs: 7, 1339) | MD, 4.15; 95% CrI, 2.03 to 6.59 (C-GAS; range 0–100)^71–73, 86, 88, 90, 95^ | Moderate; SGAs probably improve slightly^e^

C-GAS = Global Assessment Scale for Children; CGI-I = Clinical Global Impressions of Improvement; CGI-S = Clinical Global Impressions of Severity; CI = confidence interval; CrI = credible interval (used with Bayesian meta-analysis); FGA = first-generation antipsychotic; GAF = Global Assessment of Functioning; MD = mean difference; N = number; NR = not reported; PANSS; Positive and Negative Syndrome Scale; RCT: randomized controlled trial; ROB = risk of bias; RR = risk ratio; SANS = Scale for the Assessment of Negative Symptoms; SGA = second-generation antipsychotics; SMD = standardized mean difference

a When the findings are not representative of the total number of studies identified in the outcome column, we included the number of studies for each finding; we did not pool data from 1 or 2 studies so these results are always presented separately. All values except Response and Global Impressions of Functioning are favorable for group 1 (G1) when there is a negative effect estimate; the larger the magnitude of the number the larger the effect. SMDs provide results in standard deviation units, and are used when the results from different measurement tools are combined in meta-analysis; as a general rule, 0.2 represents a small effect size, 0.5 a moderate one, and 0.8 a large one.

b Downgraded for ROB and imprecision, because credible interval includes a clinically significant value (e.g., SMD ≥ ±0.50, RR ≤0.75 or ≥1.25, CGI-I or CGI-S ≥ ±2 points [0–7 point scales]) such that we could not rule out benefit even though effect estimate appears to be of no difference.

c Downgraded for ROB and imprecision because of small sample size, typically < 200 patients in total.

d CGI-S and CGI-I scores range from 0–6.

e Downgraded for ROB.

#### Key Points

- FGAs versus SGAs (six RCTs^70, 77, 81, 82, 87, 91^ and one prospective cohort study^99^): There may be little or no difference between FGAs and SGAs for negative symptoms, positive symptoms, response rates, and global impressions of illness severity. We did not have enough confidence to make any conclusions for depression symptoms or global impressions of improvement, because of high ROB and imprecision (e.g., confidence intervals including clinically meaningful estimates despite nonsignificant findings). Observations on between-study subgroup effects: (a) clozapine may have greater relative efficacy over other SGAs in comparisons with FGAs,^77^ (b) SGAs appear to have greater benefit over haloperidol than over molindone.
- Olanzapine versus risperidone (five RCTs^75, 79, 81, 82, 85^ and one prospective cohort^99^): There may be little or no difference between olanzapine and risperidone for negative and positive symptoms, response rates, and global impressions of severity. The SOE was insufficient for global functioning due to high ROB, unknown consistency, and imprecision from a small sample. Possible subgroup effects based on medication dose or treatment history appear conflicting
- Other SGA-SGA comparisons: The comparative effects are not known for several outcomes in comparisons between aripiprazole and paliperidone^94^, clozapine and olanzapine^78, 80, 98^, olanzapine and quetiapine^74^, and quetiapine and risperidone^75,84^ (all insufficient SOE). Observations on between-study subgroup effects: clozapine’s apparent benefit (though not statistically significant) over olanzapine was diminished when high-dose olanzapine was the comparator;^78^ the relative efficacy of clozapine and olanzapine is limited to studies of treatment resistance.
- SGAs—Dose comparisons (aripiprazole,^73^ asenapine,^92^ paliperidone,^90^ quetiapine,^68, 72^ risperidone,^74, 88^ and ziprasidone^65^): There may be little or no difference between low- and high-dose asenapine for response rates or global impressions of severity in the short-term. Between high and low doses of quetiapine, there appears to be little or no difference for their effects on negative symptoms or response rates; there is probably little or no difference between the doses for global impressions of severity or functioning. The comparative effects between different doses of other SGAs are not known.
- Haloperidol versus placebo (one RCT^83^): Findings from studies in this review’s time period were rated as insufficient SOE.
- SGAs versus placebo (aripiprazole,^73, 95^ asenapine,^92^ olanzapine,^76, 86^ paliperidone,^90^ quetiapine,^72^ risperidone,^88^ and ziprasidone^71^): Compared with placebo, SGAs probably decrease slightly negative and positive symptoms, increase response rates, and improve slightly global impressions of improvement, severity, and functioning. SGAs may make little or no difference for depression symptoms. The only outcome which appeared to result in a substantial magnitude of clinical benefit was response rates (RR, 1.52; 95% CrI, 1.15 to 2.02); the small magnitude for other outcomes appears to be influenced by a substantial placebo effect in many cases. Observations on between-study subgroup effects: (a) maintenance, rather than acute, treatment with aripiprazole did not appear to affect findings; (b) olanzapine may be similarly effective in treatment of schizophrenia and the prodrome phase of psychosis.

#### Detailed Analysis

This section is organized by comparison, beginning with head-to-head evidence (FGAs vs. SGAs and SGAs vs. SGAs) and followed by placebo comparisons for FGAs and SGAs.

##### FGAs Versus SGAs

Seven studies provided data on intermediate outcomes for the following FGA versus SGA comparisons: haloperidol versus clozapine,^77^ haloperidol versus olanzapine,^70, 82, 91, 99^ haloperidol versus risperidone,^82, 87, 99^ molindone versus olanzapine,^81^ and molindone versus risperidone.^81^ The comparisons between SGAs and molindone from one study^81^ were not included in the original CER because this drug was not available in the United States at that time. Average treatment duration was 10 weeks (range 6 to 19.2 weeks). The average age of the patients was 17.5 years, including one study enrolling eight young adults.^87^ In total, 299 patients were enrolled in the trials. Most patients had a diagnosis of schizophrenia; two studies enrolled some patients having schizoaffective disorder,^81, 99^ and another enrolled patients (45%) having psychoses associated with affective disorders.^82^

###### Meta-Analyses Comparing FGAs Versus SGAs

We performed meta-analysis when three or more studies (or comparisons within studies) reported on the same outcome. Meta-analyses were conducted to compare FGAs and SGAs for the short-term core symptoms of negative symptoms and positive symptoms. They were also conducted for short-term nonspecific symptoms—captured by the Brief Psychiatric Rating Scale (BPRS), Positive and Negative Syndrome Scale (PANSS) total, response rates, and rates of discontinuation for lack of efficacy—and for global impressions of improvement and severity (Clinical Global Impressions of Improvement [CGI-I] and Severity [CGI-S]).

Short-term core symptoms. Two meta-analyses of four studies found no significant differences between SGAs and FGAs on the negative (SMD, 0.0; 95% CrI, −0.55 to 0.50) or positive (SMD, −0.25; 95% CrI, −0.92 to 0.29) symptom scores of the PANSS, CPRS, and Scale for the Assessment of Negative Symptoms (SANS) (Figures 5 and 6).^77, 81, 82, 87^ Findings of no significant differences between groups in studies not used in the meta-analysis agree with the results.^91, 99^ Clozapine was more effective than haloperidol for these symptoms in the one small study of treatment-resistant patients.^77^

Figure 5 FGAs versus SGAs on negative symptoms in schizophrenia and related psychosis

CrI = credible interval; FGA = first-generation antipsychotic; SD = standard deviation; SGA = second-generation antipsychotic: SMD = standardized mean difference

Figure 5 depicts the results of a meta-analysis comparing FGAs versus SGAs on negative symptoms in schizophrenia and related psychosis. Our meta-analysis (6 trials, 254 subjects) found no significant difference between FGAs and SGAs on negative symptoms (SMD, 0.00; 95% CrI, −0.55 to 0.50; I2=10%).

Figure 6 FGAs versus SGAs on positive symptoms in schizophrenia and related psychosis

CrI = credible interval; FGA = first-generation antipsychotic; SD = standard deviation; SGA = second-generation antipsychotic: SMD = standardized mean difference

Figure 6 displays the results of a meta-analysis comparing FGAs and SGAs on positive symptoms in schizophrenia and related psychosis. Our meta-analysis (6 trials, 254 subjects) found no significant difference between first- and SGAs on positive symptoms (SMD, −0.25; 95% CrI, −0.92, to 0.29; I2=34%).

Short-term nonspecific symptoms. A meta-analysis of three studies providing data for five comparisons found no significant difference between SGAs and FGAs for overall psychiatric symptoms as measured by the BPRS total score (MD, −4.33; 95% CrI, −12.06 to 1.62) (Figure 7).^77, 81, 82^ The authors of one study did not report data for use in any meta-analysis; no significant difference was found between groups in the total symptom score on the BPRS scale.^91^ The relative effect of SGAs for this outcome appears greater in comparisons with haloperidol than with molindone.

Figure 7 FGAs versus SGAs for psychiatric symptoms on BPRS in schizophrenia and related psychosis

BPRS = Brief Psychiatric Rating Scale; CrI = credible interval; FGA = first-generation antipsychotic; MD = mean difference; SD = standard deviation; SGA = second-generation antipsychotic

Figure 7 shows a forest plot of studies reporting the mean difference of FGAs versus SGAs for psychiatric symptoms on BPRS in schizophrenia and related psychosis. This meta-analysis (5 trials, 246 subjects) found no significant difference between first- and SGAs for these symptoms (MD, −4.33; 95% CrI, −12.06 to 1.62; I2=32%).

Three RCTs provided data for a meta-analysis on the efficacy of FGAs versus SGAs on overall schizophrenia symptoms as measured by the PANSS total score (Figure 8).^70, 81, 87^ There was no significant difference between groups (MD, −2.66; 95% CrI, −14.66 to 8.53). The patients in the studies evaluating haloperidol appeared to be quite similar in terms of age and clinical characteristics; the dose of haloperidol in the study of de Haan et al.^70^ (2.5 mg/day) was lower than that used by Yen et al.^87^ (11.2 mg/day), but showed a relatively greater response. The difference may be explained by the difference in SGA. Results of no difference for this outcome were also found in the observational study not used in the meta-analysis.^99^

Figure 8 FGAs versus SGAs for schizophrenia symptoms using PANSS total score in schizophrenia and related psychosis

PANSS = Positive and Negative Syndrome Scale; CrI = credible interval; FGA = first-generation antipsychotic; MD = mean difference; SD = standard deviation; SGA = second-generation antipsychotic

Figure 8 displays a forest plot of studies reporting the mean difference of FGAs and SGAs for schizophrenia symptoms using PANSS total score in schizophrenia and related psychosis. Our meta-analysis (4 trials, 192 subjects) showed no significant difference between the efficacy of first- and SGAs on overall schizophrenia symptoms (MD, −2.66; 95% CrI, −14.66 to 8.53; I2=55%).

A meta-analysis was performed using data from four comparisons in two trials comparing response rates for SGAs and FGAs (Figure 9).^81, 82^ No difference was found (RR, 1.10; 95% CrI, 0.53 to 2.27). Another meta-analysis pooled data on discontinuations due to lack of efficacy from the same two trials, and also found no difference (RR, 0.99; 95% CrI, 0.31 to 4.01) (Figure 10).

Figure 9 FGAs versus SGAs for response rates in schizophrenia and related psychosis

CrI = credible interval; FGA = first-generation antipsychotic; RR = risk ratio; SGA = second-generation antipsychotic

Figure 9 depicts the results of a meta-analysis reporting the response rates in FGAs versus SGAs in schizophrenia and related psychosis. Our meta-analysis (4 comparisons in 2 trials) showed no difference in response rates between FGAs and SGAs (RR, 1.06; 95% CrI, 0.53 to 2.25; I2=55%).

Figure 10 FGAs versus SGAs for discontinuation due to lack of efficacy in schizophrenia and related psychosis

CrI = credible interval; FGA = first-generation antipsychotic; RR = risk ratio; SGA = second-generation antipsychotic

Figure 10 shows a meta-analysis of pooled data on discontinuation due to lack of efficacy in schizophrenia and related psychosis with use of FGAs versus SGAs. Our meta-analysis (4 comparisons in 2 trials involving 169 subjects) showed no difference between FGAs and SGAs in discontinuation due to lack of efficacy (RR, 1.01; 95% CrI, 0.28 to 4.33; I2=0%).

Short-term global impressions. Three RCTs provided data for a meta-analysis on the efficacy of FGAs versus SGAs on global impressions of improvement using the CGI–I (Figure 11).^70, 77, 82^ The pooled estimate was not significant for any difference (MD, −0.77; 95% CrI, −1.73 to 0.17). Two RCTs with four comparisons provided data for a meta-analysis on the efficacy of FGAs versus SGAs on global impressions of severity using the CGI–S (Figure 12).^81, 82^ No difference between SGAs and FGAs was found for this outcome (MD, −0.21; 95% CrI, −1.19 to 0.67).

Figure 11 FGAs versus SGAs for global impressions of improvement using CGI–I in schizophrenia and related psychosis

CGI–I = Clinical Global Impressions–Improvement; CrI = credible interval; FGA = first-generation antipsychotic; MD = mean difference; SD = standard deviation; SGA = second-generation antipsychotic

Figure 10 displays a forest plot reporting the mean difference of FGAs versus SGAs in global impressions of improvement using CGI-I in schizophrenia and related psychosis. Our meta-analysis (4 comparisons in 3 trials involving 95 subjects) showed no significant differences in global impressions of improvement between FGAs and SGAs (MD, −0.77; 95% CrI, −1.73 to 0.17; I2=0%).

Figure 12 FGAs versus SGAs for global impressions of severity using CGI–S in schizophrenia and related psychosis

CGI–S = Clinical Global Impressions–Severity; CrI = credible interval; FGA = first-generation antipsychotic; MD = mean difference; SD = standard deviation; SGA = second-generation antipsychotic

Figure 11 displays the result of a meta-analysis reporting the mean difference in global impressions of severity using CGI-S in schizophrenia and related psychosis between FGAs and SGAs. Our meta-analysis (4 comparisons in 2 trials involving 169 subjects) showed no difference in FGAs versus SGAs for global impressions of severity (MD, −0.21; 95% CrI, −1.19 to 0.67; I2=21%).

###### Additional Findings

Four studies reported on outcomes for which we did not perform meta-analysis.^70, 77, 81, 82^ Two studies reported on SGAs versus haloperidol for depression symptoms as measured by the Montgomery-Åsperg Depression Rating Scale^70^ and the BPRS^77^ (Figure 13). Clozapine had a favorable effect over haloperidol in the study of treatment-resistance conducted by Kumra et al.^77^

Figure 13 FGAs versus SGAs on depression symptoms in schizophrenia and related psychosis

FGA = first-generation antipsychotic; SD = standard deviation; SGA = second-generation antipsychotic

Figure 13 displays a meta-graph of studies reporting standard mean difference in depression symptoms in schizophrenia and related psychosis between FGAs and SGAs. The figure showed no significant difference in depression symptoms in comparisons of Clozapine versus Haloperidol (1 trial, 21 subjects; SMD, −1.26; 95% CI, −2.39 to −0.13), and Olanzapine versus Haloperidol (1 trial, 24 subjects; SMD, −1.08; 95% CI, −1.08 to 0.73).

Two comparisons within one study assessed the relative efficacy for psychiatric symptoms between two SGAs, olanzapine and risperidone, and haloperidol using the CPRS.^82^ No difference was found between SGAs and haloperidol for this outcome (Figure 14).

Figure 14 FGAs versus SGAs for psychiatric symptoms using CPRS total score in schizophrenia and related psychosis

CPRS = Conner’s Parent Rating Scale; FGA = first-generation antipsychotic; SD = standard deviation; SGA = second-generation antipsychotic

Figure 14 displays a meta-graph of studies reporting the mean difference of psychiatric symptoms (using CPRS total score) for schizophrenia and related psychosis in FGAs versus SGAs. The figure showed no significant difference in psychiatric symptoms in comparisons of Olanzapine versus Haloperidol (1 trial, 31 subjects; MD, −12.00; 95% CI −40.74 to 16.74), and Risperidone versus Haloperidol (1 trial, 34 subjects; MD, −14.00; 95% CI, −47.47 to 19.47).

Exploratory analyses in one trial showed olanzapine to produce a shorter time to response (1.6±1.3 vs. 2.4±1.3 weeks; p < 0.045 using multiple treatment comparisons) than haloperidol.^82^ There were improvements for both SGAs (olanzapine and risperidone) and molindone (range 32 to 47 percent) in functional assessment using the Children and Adolescent Functional Assessment Scale, but no differences were found between groups (p values not reported).^81^

###### Observations on Between-Study Subgroup Effects

Clozapine appears to have greater relative efficacy over other SGAs in comparisons with FGAs. This is particularly noteworthy when considering the dose of haloperidol in the study examining clozapine ^77^ was considerably higher than in the other studies (16 mg/day vs. 2.5^70^ to 11.2^87^ mg/day) comparing other SGAs to haloperidol.

From the results of two studies having similar patient populations (in terms of illness severity and treatment history) comparing SGAs olanzapine and risperidone with haloperidol^82^ and molindone,^81^ it appears that these SGAs have less relative benefit over molindone; this finding may be in part explained by the lower doses of SGAs prescribed in the study of molindone than those evaluating haloperidol (olanzapine 11.4 vs. 12.3 mg/day; risperidone 2.8 vs 4.0 mg/day).

##### SGAs Versus SGAs

Fifteen RCTs and two observational studies compared SGAs in terms of intermediate outcomes. Of these, ten studies compared different SGAs and eight compared two doses of the same SGA. Depending on the number of studies within a comparison reporting on an outcome, findings are either presented narratively or in metagraphs with or without results from meta-analyses which were conducted when data was available for three or more studies.

###### Aripiprazole Versus Paliperidone

An RCT with an 8-week acute phase and 18-week extension phase compared once-daily paliperidone extended release with aripiprazole.^94^ At 8 weeks, both groups had a similar reduction in the primary outcome of overall schizophrenia symptoms (PANSS total reduced by 19 points). There was no difference between groups for other outcomes including negative and positive symptoms, rates of response and remission, and global impressions of severity.

###### Clozapine Versus Olanzapine

Three studies (N = 88) compared clozapine with olanzapine for short-term core symptoms, nonspecific symptoms, and global impressions in treatment-resistant schizophrenia.^78, 80, 98^ The duration of the studies were 6,^98^ 8,^80^ and 12^78^ weeks. Patients were on average 14.1 years of age.

Short-term core symptoms. Two RCTs provided data on negative symptoms, measured using the SANS (Figure 15).^78, 80^ Although clozapine appeared favorable, neither study found a significant difference between the two SGAs on improvement in negative symptoms. Positive symptoms were measured by one study, with no difference between groups at study endpoint (p = 0.38).^80^ An observational study reported that its clozapine group showed a greater change from baseline for negative and positive symptoms; however, statistical comparisons between the groups were not reported.^98^

Figure 15 Clozapine versus olanzapine for negative symptoms on SANS in schizophrenia and related psychosis

SANS = Scale for the Assessment of Negative Symptoms; SD = standard deviation; RCT = randomized controlled trial

Figure 15 depicts a meta-graph of studies reporting the mean difference of negative symptoms on SANS in schizophrenia and related psychosis with use of Clozapine versus Olanzapine. Two RCTs showed non-significant favoring of Clozapine with one study (39 subjects) showing (MD, −1.90; 95% CI, −4.27 to 0.47) and the other (25 subjects) finding (MD, −11.00; 95% CI −22.53 to 0.53).

Short-term nonspecific symptoms. All three studies comparing clozapine with olanzapine reported on nonspecific symptom reduction for overall psychiatric symptoms (BPRS) and for response rates (Figures 16 and 17).^78, 80, 98^ No significant differences between the drugs were found when using the BPRS (p = 0.38,^78^ 0.42,^80^ and 0.11^98^). Kumra et al.^78^ found clozapine favorable for response rates, but the other two studies did not.

Figure 16 Clozapine versus olanzapine on overall psychiatric symptoms using the BPRS in schizophrenia and related psychosis

BPRS = Brief Psychiatric Rating Scale; RCT = randomized controlled trial; SD = standard deviation

Figure 16 shows a meta-graph reporting the mean difference of overall psychiatric symptoms in comparisons of Clozapine versus Olanzapine using the BPRS in schizophrenia and related psychosis. Although each of three comparisons (3 trials, 87 subjects) appeared to show favorability for clozapine, no significant differences in symptom reduction were found between groups.

Figure 17 Clozapine versus olanzapine for response rates in schizophrenia and related psychosis

RCT = randomized controlled trial

Figure 17 displays a meta-graph reporting response rates in comparisons of Clozapine and Olanzapine in schizophrenia and related psychosis. Response rates were not significant between groups (3 trials, 87 subjects).

Short-term global impressions. In terms of global impressions of severity, the two trials reported data on CGI–S scores (Figure 18).^78, 80^ The mean between-group effects favored clozapine for reduction in symptom severity, however neither finding was statistically significant (p = 0.24^78^ and 0.06^80^). Global assessment of functioning (Global Assessment Scale for Children [C-GAS]) showed improvement of approximately 20 points for both groups in one study without any differences between drugs (p = 0.91).^78^

Figure 18 Clozapine versus olanzapine on global impressions of severity (CGI–S) in schizophrenia and related psychosis

CGI–S = Clinical Global Impressions–Severity; SD = standard deviation

Figure 18 displays a meta-graph reporting mean difference of global impressions of severity (CGI-S) in schizophrenia and related psychosis between comparisons of Clozapine and Olanzapine. The figure showed findings of no significant differences in global impressions of severity (2 trials, 64 subjects) between groups.

Observations on between-study subgroup effects. The relatively small effects in the study by Kumra et al.^78^ may stem from the higher dose of olanzapine in this study than that reported by Shaw et al. (26.3 mg/day vs. 18.1 mg/day, respectively). When comparing clozapine to olanzapine, the effect sizes for all outcomes are numerically (if not statistically) favorable for clozapine despite a relatively high dose of olanzapine (up to 26.2 mg/day). Common for this drug, this study was targeting treatment-resistant children and it is unclear if clozapine would have even higher relative effect when used in other contexts.

###### Olanzapine Versus Quetiapine

One 12-week RCT compared olanzapine with quetiapine for intermediate outcomes.^75^ On intention-to-treat analysis, no differences were found between groups for negative (p = 0.1) and positive (p = 0.19) symptoms, overall schizophrenia symptoms (p = 0.06), response rates (p = 0.65), and global impressions of severity (p = 0.33) and functioning (p = 0.24).

###### Olanzapine Versus Risperidone

Olanzapine was compared with risperidone in six studies (N = 242) having durations between 7 and 12 weeks.^75, 79, 81, 82, 85, 99^ Patients were on average 15.8 years of age. Most studies assessed adolescents with disorders in the schizophrenia spectrum; one study enrolled patients with affective disorders who experienced psychotic symptoms (45%).^82^

Meta-analyses for olanzapine versus risperidone. Four studies provided data for meta-analyses on intermediate outcomes. Data from the RCT by Jensen et al.^75^ were only used in two of the meta-analysis.

Short-term core symptoms. Two meta-analyses were conducted for negative and positive symptoms; SMDs were generated for these outcomes using data from PANSS and CPRS measures (Figures 19 and 20).^79, 81, 82, 85^ Results found no difference between olanzapine and risperidone for these outcomes (negative symptoms: SMD, −0.09; 95% CrI, −0.76 to 0.53 and positive symptoms: SMD, −0.11; 95% CrI, −0.76 to 0.40). The results from the studies not used in the meta-analysis were also of no difference.^75, 99^

Figure 19 Olanzapine versus risperidone for negative symptoms in schizophrenia and related psychosis

CrI = credible interval; RCT = randomized controlled trial; SD = standard deviation; SMD = standardized mean difference

Figure 19 displays a forest plot of studies reporting the standard mean difference of negative symptoms in schizophrenia and related psychosis in Olanzapine versus Risperidone. Our meta-analysis (4 trials, 182 subjects) showed no significant difference in negative symptoms with use of Olanzapine versus Risperidone (SMD, −0.09, 95% CrI, −0.76 to 0.53; I2=0%).

Figure 20 Olanzapine versus risperidone for positive symptoms in schizophrenia and related psychosis

CrI = credible interval; RCT = randomized controlled trial; SD = standard deviation; SMD = standardized mean difference

Figure 20 shows the results of a meta-analysis of Olanzapine versus Risperidone for positive symptoms in schizophrenia and related psychosis. Our meta-analysis (4 trials, 182 subjects) showed no significant difference in positive symptoms with use of Olanzapine versus Risperidone (SMD, −0.11; 95% CrI, −0.76 to 0.40; I2=0%).

Short-term nonspecific symptoms. Three studies^79, 81, 82^ comparing olanzapine with risperidone reported data for psychiatric symptoms using the BPRS total score (Figure 21). The meta-analysis showed no significant difference between the two SGAs (MD, −2.56; 95% CrI, −10.19 to 4.79).

Figure 21 Olanzapine versus risperidone for psychiatric symptoms on BPRS in schizophrenia and related psychosis

BPRS = Brief Psychiatric Rating Scale; CrI = credible interval; MD = mean difference; SD = standard deviation

Figure 21 shows the results of a meta-analysis comparing Olanzapine with Risperidone for psychiatric symptoms using the Brief Psychiatric Rating Scale. Our meta-analysis (3 trials, 138 subjects) showed no significant difference in psychiatric symptoms in comparisons of Olanzapine with Risperidone (MD, −2.56; 95% CrI, −10.19 to 4.79; I2=0%).

Three meta-analyses were generated for outcomes of schizophrenia symptoms (PANSS total score), response rates, and discontinuation due to lack of efficacy (Figures 22–24). There were no differences between these SGAs for these nonspecific outcomes. Data from the RCT by Jensen et al.^75^ was not sufficient for adding to the meta-analysis on PANSS total score; this study found risperidone numerically but not statistically favorable to olanzapine (p = 0.06). An observational study^99^ also found no difference between olanzapine and risperidone groups (p = 0.14).

Figure 22 Olanzapine versus risperidone for schizophrenia symptoms on PANSS total score in schizophrenia and related psychosis

CrI = credible interval; MD = mean difference; PANSS = Positive and Negative Syndrome Scale; RCT = randomized controlled trial; SD = standard deviation

Figure 22 displays a forest plot of studies reporting the mean difference between Olanzapine and Risperidone on schizophrenia symptoms in schizophrenia and related psychosis using the Positive and Negative Syndrome Scale. Our meta-analysis (3 trials, 147 subjects) found no significant difference in schizophrenia symptoms between groups (MD, −3.51; 95% CrI, −13.18 to 5.70; I2=0%).

Figure 23 Olanzapine versus risperidone for response rates in schizophrenia and related psychosis

CrI = credible interval; RR = risk ratio

Figure 23 shows the results of a meta-analysis comparing response rates in schizophrenia and related psychosis between Olanzapine and Risperidone. Our meta-analysis (4 trials, 182 subjects) found no difference for the outcome of response rate between these two SGAs (RR, 1.01; 95% CrI, 0.51 to 1.90; I2=30%).

Figure 24 Olanzapine versus risperidone for discontinuation for lack of efficacy in schizophrenia and related psychosis

CrI = credible interval; RR = risk ratio

Figure 24 displays a meta-analysis of studies reporting the risk ratio for discontinuation for lack of efficacy in schizophrenia and related psychosis between Olanzapine versus Risperidone. Our meta-analysis (4 trials, 182 subjects) found no significant difference for discontinuation for lack of efficacy with use of Olanzapine versus Risperidone (RR, 0.77; 95% CrI, 0.19 to 3.05; I2=0%).

Additional findings. One RCT found no difference between olanzapine and risperidone for overall psychiatric symptoms using the CPRS (p = 0.86).^82^ There was no difference between groups in one RCT for outcomes of medication adherence and remission.^85^ Nonadherence did not differ between the two treatment groups in the observational study.^99^

Two RCTs provided scores for global impressions of severity using the CGI–S score (Figure 25).^81, 82^ Both studies found no difference between olanzapine and risperidone. Jensen et al.^75^ reported the proportion of patients who attained a certain CGI–S threshold instead of the change scores; the results of this study showed no difference between drugs. Global impressions of functioning, measured by C-GAS, did not differ by groups at study end point in the studies of Mozes et al. (p = 0.44),^79^ and Jensen et al. (p = 0.24).^75^

Figure 25 Olanzapine versus risperidone for global severity using CGI–S in schizophrenia and related psychosis

CGI–S = Clinical Global Impressions–Severity; SD = standard deviation

Figure 25 shows the results of a meta-analysis reporting the mean difference of global severity using CGI-S in schizophrenia and related psychosis with use of Olanzapine versus Risperidone. Our meta-analysis (2 trials, 113 subjects) found no significant difference between Olanzapine and Risperidone on global impressions of severity (MD, 0.30; 95% CrI, −1.18 to 1.79; I2=0%).

Observations on between-study subgroup effects. Possible influences of treatment effect based on dose or treatment history appear conflicting. The study by Mozes et al.^79^ appears to be an outlier favoring olanzapine; although the dose of olanzapine was relatively low in this study (8.2 mg/day), 96 percent of the patient population was treatment naïve. A trend favoring olanzapine for treatment naïve patients was not found by the study by Jensen et al.^75^ having a largely treatment naïve (77%) population, in which PANSS total scores and response rates numerically favored risperidone (PANSS, p = 0.06; response rates, 70% vs. 50%).

###### Quetiapine Versus Risperidone

Two RCTs compared quetiapine with risperidone for intermediate outcomes in mainly (>75%) treatment naïve patient populations. A 6-week RCT^84^ (N = 22) found no significant differences between the risperidone and quetiapine groups for the primary outcomes of 30 percent or more reduction in PANSS (p = 0.66), BPRS (p = 1.0), CGI-S (p = 1.0), or the Hamilton Depression Rating Scale (HAM-D; p = 0.64). Some benefit favoring risperidone over quetiapine was found when comparing percentage of patients improving by at least one level on the CGI-S (72.7% vs. 45.5%), or by at least 10 points on the HAM-D (50% vs. 20%). No significant difference was found between the groups for medication adherence.

A 12-week RCT comparing olanzapine, quetiapine, and risperidone found no differences between groups for negative (p = 0.1) and positive (p = 0.19) symptoms, overall schizophrenia symptoms (p = 0.06), response rates (p = 0.65), and global impressions of severity (p = 0.33) and functioning (p = 0.24).^75^

Data by treatment group was not provided by one study^75^ to enable presentation of findings for most outcomes from both studies in metagraphs. Results for response rates and for discontinuation due to lack of efficacy are presented in Figures 26 and 27.

Figure 26 Quetiapine versus risperidone on response rates in schizophrenia and related psychosis

Figure 26 displays a meta-graph of studies reporting the response rates in schizophrenia and related psychosis in comparisons between Quetiapine versus Risperidone. Two studies (52 participants) reported no difference between groups.

Figure 27 Quetiapine versus risperidone on discontinuation due to lack of efficacy in schizophrenia and related psychosis

Figure 27 displays a meta-graph of studies comparing the difference of Quetiapine versus Risperidone on discontinuation due to lack of efficacy in schizophrenia and related psychosis. Our meta-graph shows two studies (52 participants) found no difference between groups.

Aripiprazole—Low- versus high-dose. A 6-week RCT enrolled 302 adolescents with schizophrenia to compare low- or high-dose aripiprazole with placebo.^73^ Twenty-six percent of patients were treatment naïve. No significant differences occurred between the low- and high-dose aripiprazole groups for negative (p = 0.72), positive (p = 0.56), and general psychotic symptoms (p = 0.37), and for global impression of improvement (p = 0.16), severity (p = 0.48), and functioning (p = 0.96).

Asenapine—Low versus high-dose. An 8-week RCT (N = 306) compared asenapine 2.5 mg twice daily, asenapine 5.0 mg twice daily, and placebo.^92^ Approximately 68 percent had previous antipsychotic exposure, although none had been on clozapine. There was no difference between the two doses of asenapine for the PANSS total score (p = 0.83), CGI-S scores (p = 0.2), or response based on ≥30 percent reduction in PANSS total score (p = 0.99).

Paliperidone–Low- versus medium- versus high-dose. Singh et al.^90^ compared three doses of extended-release paliperidone and placebo in a 6-week RCT (N = 201). There were no differences between doses for negative symptoms (p > 0.10). Compared with the low dose group, the medium, but not high, dose achieved greater reduction in positive symptoms (3 points on PANSS; p = 0.01) and overall schizophrenia symptoms (7.5 points on PANSS; p = 0.03), and a higher response rate (64.6% vs. 38.9%; p = 0.001). Both medium and high doses reduced illness severity (1 point on CGI-S; p < 0.001 for medium and p = 0.02 for high) and improved global functioning (> 4 points on C-GAS; p < 0.05) compared with the low dose.

Quetiapine–Low- versus high-dose. Two RCTs compared two doses of quetiapine. Berger et al.^67^ examined 141 drug-naïve patients with first-episode psychosis in a 4-week RCT comparing quetiapine doses of 200 and 400 mg/day. There was no difference between groups noted for negative symptoms (p = 0.62), overall psychiatric symptoms (p = 0.15), or global impressions of severity (p = 1.00) or functioning (p = 0.12).

A 6-week placebo-controlled RCT (N = 222) examined the efficacy of low- (400 mg/day) and high-dose (800 mg/day) quetiapine.^71^ No significant differences were found between the low- and high-dose groups for outcomes of core and general symptoms (p > 0.40); depression/anxiety (p = 0.65); response rates (p = 0.81); or global impressions of severity (p = 0.46), improvement (p = 0.38), or functioning (p = 0.38). Medication adherence rates were also similar (> 96%).

Risperidone–Low- versus high-dose. An 8-week RCT compared the efficacy of low- (0.4 mg/day) and high-dose (4 mg/day) risperidone in 275 adolescents.^74^ The high-dose risperidone group showed greater improvement than the low-dose group for negative, positive, and overall schizophrenia symptoms; response rates; and for global impressions of improvement and severity (p < 0.005 for all).

A 6-week placebo-controlled RCT (N = 158) compared the efficacy of low- (1–3 mg/day) and high-dose (4–6 mg/day) risperidone.^88^ No significant differences were observed between the two dosing groups for negative, positive and overall schizophrenia symptoms (p > 0.6 for all); rates of response or discontinuation for lack of efficacy (p > 0.4); and for global impressions of improvement (p = 0.74), severity (p = 0.24), and functioning (p = 0.56).

Ziprasidone–Low- versus high-dose. DelBello et al.^65^ conducted a 3-week RCT comparing the efficacy of low- (80 mg/day) and high-dose (160 mg/day) ziprasidone for treating bipolar mania, schizophrenia, and schizoaffective disorder. Separate analyses were provided for the 17 patients with schizophrenia. No significant differences were found between the low- and high-dose groups for overall psychiatric symptoms (p = 0.21), or global impressions of severity (p = 0.8).

##### FGAs Versus Placebo

An 8-week crossover RCT (N = 16) compared haloperidol with placebo in children ages 5 to 11 with schizophrenia.^83^ Both the positive and negative syndrome scores on the CPRS improved significantly in the haloperidol group compared with the placebo group (p < 0.01). Statistical comparisons between the two groups were not possible (no variances reported) for overall psychiatric symptoms, or global improvement and severity.

##### SGAs Versus Placebo

Nine RCTs (N = 1788) compared an SGA with placebo for intermediate outcomes: aripiprazole,^72, 95^ asenapine,^92^ olanzapine,^76, 86^ paliperidone,^90^ quetiapine,^72^ risperidone,^88^ and ziprasidone.^71^ The average age of patients across studies was 15.8 years and 62 percent were males; 7 studies reporting on race/ethnicity enrolled 39.2 percent minorities. Studies were either 6 or 8 weeks’ duration, with the exception of the unpublished study^95^ from which we extracted 24-week followup data. The only study that reported a large proportion (90%) of the study population as being treatment naïve was that examining the prodromal phase.^86^

###### Meta-Analyses Comparing Various SGAs With Placebo

Meta-analyses were conducted to compare various SGAs versus placebo for the short-term core symptoms of negative symptoms, positive symptoms, and depression. They were also conducted for short-term nonspecific symptoms—captured by the BPRS, PANSS total, response rates, and rates of discontinuation for lack of efficacy—and for global impressions of improvement (CGI-I), severity (CGI-S), and functioning (C-GAS, Global Assessment of Functioning [GAF]). Four studies also contributed to a meta-analysis for medication adherence.

When a study had two or more arms with patients taking different doses of the same drug, we combined data from all arms; the studies in general did not report any difference in effect between doses of the same drug. We realize this strategy may mask a greater or lesser effect when prescribing lower or higher doses to individual patients.

We conducted sensitivity analysis for some analyses, because of clinical heterogeneity related to a priori specified factors of phase of illness and treatment history. The study reported by Woods et al.^86^ on use of olanzapine in the prodromal phase of psychosis, and the trial examining discontinuation of aripiprazole in patients stabilized on this drug^95^ were removed from several analyses to examine whether results differed.

Short-term core symptoms. Nine RCTs contributed data for meta-analyses for negative (Figure 28) and positive (Figure 29) symptoms measured using the PANSS.^71–73, 76, 86, 88, 90, 92, 95^ Both results showed statistically significant differences between SGAs and placebo (negative symptoms: MD, −1.31; 95% CrI, −2.05 to −0.58, and positive symptoms: MD, −2.20; 95% CrI, −2.98 to −1.48). Sensitivity analyses removing the studies examining the prodromal phase (Woods et al.^86^) and the maintenance after stabilization on the SGA (NCT01149655^95^) did not change the results in a meaningful manner for negative or positive symptoms (MD, −1.41; 95% CrI, −2.38 to −0.51 and MD, −2.19; 95% CrI, −3.18 to −1.31, respectively).

Figure 28 SGAs versus placebo for negative symptoms on PANSS in schizophrenia and related psychosis

CrI = credible interval; MD = mean difference; PANSS = Positive and Negative Syndrome; SD = standard deviation; SGA = second generation antipsychotic

Figure 28 displays a meta-analysis of studies reporting the mean difference for negative symptoms on PANSS in schizophrenia and psychosis with use of SGAs versus placebo. Our meta-analysis (9 trials, 1685 subjects) showed a significant difference in negative symptoms with use of SGAs versus placebo (MD, −1.31; 95% CrI, −2.05 to −0.58; I2=15%).

Figure 29 SGAs versus placebo for positive symptoms on PANSS in schizophrenia and related psychosis

CrI = credible interval; SD = standard deviation; MD = mean difference; PANSS = Positive and Negative Syndrome Scale; SGA = second generation antipsychotic

Figure 29 displays a meta-analysis of studies reporting the mean difference for positive symptoms on PANSS in schizophrenia and related psychosis with use of SGAs versus placebo. Our meta-analysis (9 trials, 1685 subjects) showed a significant difference in positive symptoms with use of SGAs versus placebo (MD, −2.20; 95% CrI, −2.98 to −1.48; I2=0%).

Two RCTs contributed data on depression symptoms from the PANSS (Figure 30).^72, 90^ No difference was shown between the SGAs paliperidone (p = 0.19) or quetiapine (p = 0.18) and placebo.

Figure 30 SGAs versus placebo for depressive symptoms on PANSS in schizophrenia and related psychosis

PANSS = Positive and Negative Syndrome Scale; SD = standard deviation; SGA = second generation antipsychotic

Figure 30 displays a meta-graph of studies reporting the mean difference of depressive symptoms on PANSS in schizophrenia and related psychosis with use of SGAs versus placebo. Results were similar and not statistically significant for Paliperidone versus placebo (1 trial, 147 subjects; MD, −0.59; 95% CrI, −1.46 to 0.28) and Quetiapine versus placebo (1 trial, 222 subjects; MD, −0.59; 95% CrI, −1.45 to 0.27).

Short-term nonspecific symptoms. All nine RCTs^71–73, 76, 86, 88, 90, 92, 95^ reported overall symptoms of schizophrenia using the PANSS total score and were combined in a meta-analysis (Figure 31). The pooled estimate found SGAs to be superior to placebo in reducing overall schizophrenia symptoms (MD, −5,71; 95% CrI, −8.09 to −3.53); no effect was seen on sensitivity analysis. The effect size of approximately a 6-point reduction is lower than most reports defining a clinically meaningful value of at least 10 points or ≥ 20 percent reduction; many studies had inclusion criteria of baseline PANSS total scores in the 60–80 range. The placebo groups in several studies experienced clinically relevant improvements.

Figure 31 SGAs versus placebo for overall schizophrenia symptoms using PANSS Total score in schizophrenia and related psychosis

CrI = credible interval; MD = mean difference; PANSS = Positive and Negative Syndrome Scale; SD = standard deviation; SGA = second generation antipsychotic

Figure 31 shows a meta-analysis of studies reporting the mean difference of overall schizophrenia symptoms using PANSS Total score in schizophrenia and related psychosis with use of SGAs versus placebo. Our meta-analysis (9 trials, 1685 subjects) showed a significant difference in overall symptoms (MD, −5.71; 95% CrI, −8.09 to −3.53; I2=0%).

Three RCTs compared SGAs (olanzapine,^76^ ziprasidone,^71^ and quetiapine^72^) with placebo for overall psychiatric symptoms using BPRS scores (Figure 32). These drugs reduced symptoms to a greater extent than placebo (MD, −3.80; 95% CrI, −6.64 to −1.27). There was moderate heterogeneity (I^2^ = 65%) in the analysis which may be in part due to the different SGAs.

Figure 32 SGAs versus placebo for overall psychiatric symptoms on BPRS in schizophrenia and related psychosis

BPRS = Brief Psychiatric Rating Scale; CrI = credible interval; MD = mean difference; SD = standard deviation; SGA = second generation antipsychotic

Figure 32 displays a meta-analysis of studies reporting the mean difference for overall psychiatric symptoms on BPRS in schizophrenia and related psychosis with use of SGAs versus placebo. Our meta-analysis (3 trials, 566 subjects) showed that improved overall psychiatric symptoms improved for persons receiving SGAs versus those receiving placebo (MD, −3.80; 95% CrI, −6.64 to −1.27; I2=65%).

Five RCTs reported response rates for SGAs versus placebo (Figure 33).^72, 76, 88, 90, 92^ The estimated RR was 1.52 (95% CrI, 1.15 to 2.02) showing greater response for SGAs compared with placebo. Data from six RCTs also found the SGAs favorable over placebo for having lower rates of discontinuation for lack of efficacy (RR, 0.38; 95% CrI, 0.20 to 0.88) (Figure 34).^71, 73, 76, 88, 90, 92^

Figure 33 SGAs versus placebo for response rates in schizophrenia and related psychosis

CrI = credible interval; RR = risk ratio; SGA = second generation antipsychotic

Figure 33 displays a meta-analysis of studies reporting response rates for SGAs versus placebo in schizophrenia and related psychosis. Our meta-analysis (5 trials, 1036 subjects) showed a greater response for SGAs compared with placebo (RR, 1.52; 95% CrI, 1.15 to 2.02; I2=0%).

Figure 34 SGAs versus placebo for discontinuation due to lack of efficacy in schizophrenia and related psychosis

CrI = credible interval; RR = risk ratio; SGA = second generation antipsychotic

Figure 34 displays a meta-analysis of studies reporting discontinuation due to lack of efficacy in schizophrenia and related psychosis with use of SGAs versus placebo. Our meta-analysis (6 trials, 1257 subjects) found the SGAs favorable over placebo for having lower rates of discontinuation for lack of efficacy (RR, 0.38; 95% CrI, 0.20 to 0.88; I2=45%).

Short-term global impressions. Six RCTs comparing aripiprazole,^73, 95^ olanzapine,^76^ risperidone,^88^ quetiapine,^72^ and ziprasidone^71^ with placebo reported on global impressions of improvement using CGI–I scores (Figure 35). The pooled estimate significantly favored SGAs over placebo (MD, −0.54; 95% CrI, −1.07 to −0.14). Removing the maintenance study (NCT01149655^95^) did not affect the effect estimate although broadened the credible interval slightly (−1.28 to −0.07). There was moderate statistical heterogeneity between the studies (I^2^ = 64%), which may have been driven by differences between the SGA comparators.

Figure 35 SGAs versus placebo for symptom improvement using the CGI–I in schizophrenia and related psychosis

CGI-I = Clinical Global Impression of Improvement; CrI = credible interval; MD = mean difference; SD = standard deviation; SGA = second generation antipsychotic

Figure 35 displays a meta-analysis of studies reporting the mean difference of symptom improvement using the CGI-I in schizophrenia and related psychosis with use of SGAs versus placebo. Our meta-analysis (6 trials, 1176 subjects) showed favorability of SGAs over placebo (MD, −0.58; 95% CrI, −0.98 to −0.28; I2=54%).

All nine studies provided data for a meta-analysis comparing SGAs with placebo for global impression of severity (CGI-S) (Figure 36). Patients treated with SGAs had a greater reduction in illness severity than those receiving placebo (MD, −0.36; 95% CrI, −0.51 to −0.22). Sensitivity analysis removing the two studies having clinical heterogeneity (Woods^86^ and NCT01149655^95^) did not affect the results appreciably (MD, −0.38; 95% CrI, −0.58 to −0.21).

Figure 36 SGAs versus placebo for symptom severity using the CGI–S in schizophrenia and related psychosis

CGI-S = Clinical Global Impression of Severity; CrI = credible interval; MD = mean difference; SGA = second generation antipsychotic; SD = standard deviation

Figure 36 displays a meta-analysis of studies reporting mean difference of symptom severity using the CGI-S in schizophrenia and related psychosis with use of SGAs versus placebo. Our meta-analysis (9 trials, 1685 participants) found patients treated with SGAs had a greater reduction in symptom severity than those receiving placebo (MD, −0.41; 95% CrI, −0.56 to −0.27; I2=0%).

Seven RCTs^71–73, 86, 88, 90, 95^ contributed data to a meta-analysis comparing SGAs with placebo for global impressions of function measured by the C-GAS (Figure 37). With the exception of two studies examining olanzapine,^86^ and ziprasidone^71^ all trials significantly favored the SGAs. The pooled estimate showed a significant improvement in functioning for SGAs compared with placebo (MD, 4.15; 95% CrI, 2.03 to 6.59). Our sensitivity analysis showed minimal changes when removing the Woods et al. and NCT01149655 trials^86, 95^ (MD, 4.32; 95% CrI, 1.28 to 8.06).

Figure 37 SGAs versus placebo for global functioning using the C-GAS in schizophrenia and related psychosis

C-GAS = Children’s Global Assessment Scale; CrI = credible interval; SD = standard deviation; SGA = second-generation antipsychotic; MD = mean difference

Figure 37 shows the results of a meta-analysis comparing SGAs with placebo for global impressions of function measured by the C-GAS in schizophrenia and related psychosis. Our meta-analysis (9 studies, 1685 participants) showed preference for SGAs compared with placebo (MD, −0.41; 95% CrI, −0.56 to −0.27; I2=0%).

Medication adherence. Four RCTs examining olanzapine,^76, 86^ paliperidone,^90^ and quetiapine^72^ provided data on medication adherence (Figure 38). No difference between the SGAs and placebo in terms of poor adherence rates was found (RR, 1.39; 95% CrI, 0.36 to 5.39).

Figure 38 SGAs versus placebo on poor medication adherence in schizophrenia and related psychosis

CrI = credible interval; RR = risk ratio; SGA = second-generation antipsychotic

Figure 38 depicts the results of a meta-analysis comparing SGAs versus placebo on poor medication adherence in schizophrenia and related psychosis. Our meta-analysis (4 trials, 536 subjects) showed no difference between SGAs and placebo in terms of poor adherence rates (RR, 1.39; 95% CrI, 0.36 to 5.39; I2=0%).

Lifestyle behaviors. Three RCTs^72, 76, 86^ reported on the number of patients experiencing an increase in appetite; because of the concerns about excessive weight gain for children taking antipsychotics we considered an increase in appetite to be a negative finding for SGAs. Figure 39 displays the findings for our analysis which showed no statistically significant difference between SGAs and placebo (RR, 1.71; 95% CrI, 0.51 to 5.66). Although the relative effect was not statistically significant, in all studies there were more patients in the treatment than placebo group experiencing increased appetite.

Figure 39 SGAs versus placebo for increased appetite in schizophrenia and related disorders

CrI= credible interval; RR = risk ratio; SGA = second-generation antipsychotic

Figure 39 shows the findings for a meta-analysis comparing SGAs versus placebo for increased appetite in schizophrenia and related psychosis. Our meta-analysis (3 trials, 389 subjects) showed no statistically significant difference between SGAs and placebo for increased appetite (RR, 1.71; 95% CrI, 0.51 to 5.66; I2=0%).

###### Observations on Between-Study Subgroup Effects

One study randomized patients to maintenance or discontinuation of aripiprazole after treatment stabilization; inclusion criteria was response to aripiprazole.^95^ Patients starting a trial with less severity of illness than patients in other studies may limit the degree of potential change, even relative to placebo. As per protocol, we extracted data from this study’s results at 24 weeks which was the longest followup within this short-term stratum of 0 to <6 months; these longer term results may have increased the relative effects between treatment and placebo. Sensitivity analyses in the meta-analyses including data from this trial did not change the results.

Combining results from studies enrolling severely ill patients with schizophrenia with those enrolling high-risk, but undiagnosed, outpatients may confound results. We performed sensitivity analyses for the meta-analysis including data from the trial investigating the prodromal phase (Woods et al.^86^) the difference in results was negligible.

### Schizophrenia and Related Psychoses: Effectiveness Outcomes

Fourteen studies reported on effectiveness outcomes for treating schizophrenia and related psychosis. A summary of the key findings by comparison is provided below. Table 6 contains the findings and SOE ratings for the key outcomes assessed as having at least low SOE; the reason for each SOE decision is included in the table footnotes. A detailed analysis follows.

Table 6 Strength of evidence for schizophrenia and related psychosis: Key effectiveness outcomes having at least low strength of evidence

Comparison | Outcome (N Studies; N Patients) | Findings^a^ and Studies | Strength of Evidence; Conclusions
SGAs vs. placebo | Short-term suicide attempts/suicides (7, 1463) | Attempts: 2 in 693 SGA and 2 in 318 placebo patients ^71, 72, 90, 92^ Suicides: 0 in 447 SGA vs. 0 in 227 placebo patients^72, 73, 88^ | Low; may make little or no difference ^b^
SGAs vs. placebo | Short-term suicide ideations or behaviors (4, 758) | Ideations: 3 in 340 SGA and 1 in 165 placebo patients^71, 72^ Behaviors: 1 in 170 SGA and 1 in 83 placebo patients^76, 95^ | Low; may make little or no difference ^b^

N = number; ROB = risk of bias; SGA = second-generation antipsychotics

a There were no meta-analyses conducted for these findings because of 0 events in some studies; there were no outcomes with ≥ 3 studies having events.

b Downgraded for ROB and imprecision because of small event rates; confidence intervals of relative risks ranged between 0.02 to 5.0, to 0.06 to 48.1).

#### Key Points

- FGAs versus SGAs (two RCTs^70, 81^ and one prospective cohort^102^): The effects are not known for several effectiveness outcomes in studies between FGAs and SGAs (insufficient SOE). Apart from long-term symptom scores, only two studies reported on other effectiveness outcome including global functioning, suicide and subjective wellbeing
- Different SGAs: aripiprazole versus paliperidone (one RCT^94^), olanzapine versus quetiapine (one RCT^67^), olanzapine versus risperidone (one RCT^81^ and three observational studies^101, 102, 104^), risperidone versus quetiapine (two observational studies^101, 104^), clozapine versus other SGAs (one prospective cohort^102^). It is not known whether there is any difference between various SGAs for effectiveness outcomes, including long-term core and nonspecific outcomes, global impressions, personal and social performance, suicide ideations, occupational functioning and functioning in the family, and inpatient psychiatric admissions.
- SGAs—Dose comparisons (aripiprazole,^73^ quetiapine,^68, 72^ and risperidone^88^): The comparative effects between different doses are not known for outcomes of quality of life, caregiver strain, social and occupational functioning, hospital admission rates, imprisonments, suicide ideations/behaviors, or deaths by suicide.
- SGAs versus placebo (five RCTs^72, 73, 86, 93, 95^): There may be little or no difference between SGAs and placebo for suicide attempts, completed suicide, suicide ideations, or suicide behaviors in short-term studies.^71–73, 76, 88, 90, 92, 95^ The effects from long-term maintenance on aripiprazole are not known for positive symptoms, relapse rates, response and remission rates, global impressions of improvement, changes in illness severity or functioning, or suicide behaviors. For patients experiencing the prodrome phase, the effects are not known for long-term negative, positive, or depression symptoms; rates of 12-month transition to psychosis; global impression of severity or functioning; or for quality of life. SOE was insufficient because of high ROB and imprecision from small samples and confidence intervals including possibility for substantial benefit for either group. The effects on caregiver strain are not known for patients taking low- or high- dose quetiapine.^72^

#### Detailed Analysis

##### FGAs Versus SGAs

Three studies reported on effectiveness outcomes when comparing FGAs with SGAs.^70, 81, 102^ A brief description of the long-term studies is presented before summarizing the effectiveness outcomes by category.

###### Description of Long-Term Studies

Haloperidol versus olanzapine, risperidone, and clozapine. A prospective cohort study evaluated long-term efficacy and safety of an FGA (haloperidol) and SGAs (olanzapine, risperidone, clozapine) in patients (N = 47) with early-onset psychosis who were followed between 3 and 11 years.^102^ Patients were treated using a clinical algorithm, whereby haloperidol was first-line treatment during 1990 and 1999 before risperidone or olanzapine were preferred between 2000 and 2005.

Molindone versus risperidone and olanzapine. A 44-week double-blind extension (N = 54) of the 8-week study by Sikich et al.^81^ maintained patients showing improvement during the 8-week acute phase on flexibly dosed molindone, risperidone, or olanzapine.

###### Results on Effectiveness Outcomes From Short- and Long-Term Studies

Long-term core symptoms. Over 3 year followup, patients taking haloperidol and SGAs all showed clinical improvement but clozapine was more effective for negative and positive symptoms than haloperidol (p < 0.0001) and risperidone was favored over haloperidol for positive symptoms (p < 0.03).^102^ Similar to the RCT’s acute phase, 52-week followup found no differences between molindone, olanzapine, and risperidone for negative and positive symptoms;^81^ significant differences seen in responders at 8-weeks remained stable over the long-term.

Long-term nonspecific symptoms. Clozapine and risperidone were more effective than haloperidol for overall symptoms measured using the PANSS scale (p values < 0.0001 and 0.03, respectively).^102^ Clozapine was more effective than haloperidol for response rates (p < 0.001); all three SGAs were superior to haloperidol for rates of discontinuation due to lack of efficacy (p < 0.003).^102^ The RCT comparing molindone to SGAs found no differences between drugs for long-term overall schizophrenia symptoms;^81^ no group achieved more than a 7-point reduction in the PANSS total score.

Long-term global impressions. Global impressions of illness severity (CGI-S) were no different between molindone, risperidone, and olanzapine at 52-week followup;^81^ the changes of about 2 points reduction seen at 8-weeks were maintained in this subgroup of patients. Global functioning measured using the Child and Adolescent Functional Assessment Scale was worse for the risperidone group than the molindone group (p = 0.025).^81^ In the observational study, clozapine was favored over haloperidol in terms of overall functioning measured using the GAF or C-GAS (p < 0.01).^102^

Suicide-related ideations and behaviors. One RCT reported on suicide ideation, with no patients reporting these in any group.^81^

Occupational functional capacity. No findings specific to FGA-SGA comparisons were reported; at 5-year followup 6 of 19 patients on clozapine and 5 of 20 patients on other antipsychotics (including haloperidol) had completed school and were able to work.^102^

Quality of life. A 6-week RCT comparing haloperidol with olanzapine assessed patients for wellbeing using the Subjective Well-Being Under Neuroleptics Scale.^70^ This outcome improved from baseline to endpoint in both groups; however, there was no significant difference (p = 0.26) between the groups.

##### SGAs Versus SGAs

Six studies (3 RCTs^67, 81, 94^ and 3 observational studies^101, 102, 104^) compared different SGAs for effectiveness outcomes. Three RCTs compared different doses of an SGA;^72, 73, 75^ none of these dose comparisons reported on long-term symptom or global impression outcomes (≥ 6 months) but they reported on other effectiveness outcomes (e.g., quality of life, cognitive effects).

Aripiprazole versus paliperidone. An RCT with an 8-week acute phase and 18-week extension phase compared once-daily paliperidone extended release with aripiprazole in patients with prior exposure to antipsychotics.^94^ At 26 weeks, both groups had a similar reduction (p = 0.877) in the primary outcome of overall schizophrenia symptoms (PANSS total reduced by 26 points). More than 50 percent of patients in both groups remained clinically stable (p = 0.30). There was no difference between groups for other long-term outcomes including negative (p = 0.7) and positive (p = 0.4) symptoms, global impressions of severity (p = 0.91), and personal and social performance (p = 0.71). Two patients in the paliperidone group had suicide ideations and attempted suicide; four patients in the paliperidone group and two in the aripiprazole group had suicide related events.

Olanzapine versus quetiapine. A 6-month RCT (N = 50) enrolled adolescents experiencing a first episode of psychosis.^67^ There was a significant difference between the groups favoring olanzapine for Strengths and Difficulties Questionnaire as rated by patients (p = 0.03); the results for the ratings by parents and teachers were not significant. No differences were found for the negative (p = 0.34), positive (p = 0.12), and overall symptoms (p = 0.4); depression symptoms (p = 0.66); or global impressions of severity (p = 0.6) or functioning (p = 0.12). Results for adherence and performance on various cognitive domains (attention, working memory, learning and memory, and executive functions) were also of no difference.

Olanzapine versus risperidone. A 44-week double-blind extension (N = 54) of the study by Sikich et al.^81^ maintained patients showing improvement during the 8-week acute phase on flexibly dosed molindone, risperidone, or olanzapine. No differences between groups were found for changes in clinical outcomes from baseline to 52 weeks; changes in global functioning as measured using the Child and Adolescent Functional Assessment Scale were worse for the risperidone group than the olanzapine group during the maintenance phase (p = 0.025). In the risperidone group, one patient reported suicidal ideation, and one patient died by suicide.

Olanzapine versus risperidone versus clozapine. A prospective cohort study evaluated the 3- to 11- year efficacy and safety of haloperidol, olanzapine, risperidone, and clozapine.^102^ For negative, positive, and overall symptoms measured using the PANSS scale, clozapine was more effective than the other SGAs (p < 0.0001). Similar results occurred for response rates, measured via ≥ 20 percent reduction in PANSS total scores and being “improved” or “very improved” on the CGI-I, and for discontinuation due to lack of efficacy. Clozapine was also favored over the other drugs in terms of overall functioning measured using the GAF or CGAS (p < 0.01).

Risperidone versus quetiapine versus olanzapine. A 24-month prospective cohort study recruited 110 consecutive children and adolescents having first-episode psychotic disorder (23 percent with affective psychoses).^101^ Patients were assessed for negative, positive and overall psychotic symptoms (PANSS); global impressions of improvement, severity, and functioning (CGI and GAF); and for occupational functioning and functioning in the family and social environments (World Health Organization Disability Assessment Schedule). When looking at patients who only received one antipsychotic for 6 months (N = 60), all had significantly improved responses on all scales (p < 0.005) with the exception of those taking risperidone who did not improve in terms of negative symptoms (p = 0.530). There were no differences between groups for any outcome (p values ranging from 0.07 for functioning and disability to > 0.2 for core and nonspecific symptoms). Overall rates and reasons for discontinuation over the 24 months were not different between groups; 71 percent of patients discontinued their first antipsychotic treatment. Insufficient response was the most frequent reason for discontinuation at all timepoints.

Risperidone versus olanzapine, quetiapine, aripiprazole, and ziprasidone. A 6-month retrospective cohort study (N = 1745) using a 45-state Medicaid Claims database examined patients having early-onset schizophrenia prescribed antipsychotic monotherapy with an SGA between 2011–2005.^104^ Most (71% for quetiapine to 77% for aripiprazole) youth discontinued their medication within the first 6 months of treatment. Compared with risperidone, the adjusted hazards of antipsychotic discontinuation did not significantly differ for any comparator. Inpatient psychiatric treatment ranged from 7.19 percent (aripiprazole) to 9.89 percent (quetiapine), although there were no treatment differences between risperidone and the other SGAs (p = 0.94).

Aripiprazole—Low- versus high-dose. Findings for quality of life measured using the Pediatric Quality of Life Enjoyment and Satisfaction Questionnaire were similar between the low- and high-dose aripiprazole groups in one 6-week RCT.^73^

Quetiapine–Low- versus high-dose. Two RCTs examined patients for effectiveness outcomes from taking different doses of quetiapine. Measurement using the Social and Occupational Functioning Assessment Scale showed significantly greater improvement in one low-dose (200 mg/day) group although this group started at a lower level of baseline functioning.^68^ Hospital admission rate was significantly lower in the high-dose (400 mg/day) group (p = 0.005); days in hospital did not differ between groups. There was also no difference in imprisonments or deaths by suicide. In the other RCT, there was significantly greater reduction in scores on the Caregiver Strain Questionnaire for the low-dose (400 mg/day) but not high-dose (600 mg/day) quetiapine group compared with placebo (p = 0.008).^72^

Risperidone–Low- versus high-dose. In an 8-week RCT comparing the efficacy of low- (0.4 mg/day) and high-dose (4 mg/day) risperidone, no patient attempted suicide; however, two patients in the low-dose risperidone group reported suicidal ideation.^79^

##### FGAs Versus Placebo

An 8-week crossover RCT (N = 16) comparing haloperidol (2 mg/day) with placebo in children ages 5 to 11 years with schizophrenia did not report on any effectiveness outcomes.^83^

##### SGAs Versus Placebo

Five RCTs examined effectiveness outcomes for SGAs compared with placebo.^72, 73, 86, 93, 95^ Three of these studies reported long-term outcomes.^86, 93, 95^

###### Description of Long-Term Studies

Aripiprazole versus placebo. A 52-week RCT (N = 146) examined maintenance with aripiprazole (10–30 mg/day) compared with placebo in adolescent patients who were previously stabilized on aripiprazole (previously described).^95^

Olanzapine versus placebo. An RCT (N = 60) comparing olanzapine (8±3.1 mg/day) with placebo in patients (ages 12 to 45 years, mean age of 17.7 years) with prodromal syndrome included data for 8 and 52 weeks.^86^

Risperidone versus placebo. A 12-month RCT examined the addition of risperidone (n = 43) or placebo (n = 44) to cognitive behavioral therapy in patients ages 14–30 (mean ages 17.6 ±3.0 and 18.0±2.7, respectively) experiencing the prodromal phase of psychosis.^93^

###### Results on Effectiveness Outcomes From Short- and Long-Term Studies

Long-term core symptoms. Comparing maintenance aripiprazole to placebo, both groups experienced more positive symptoms at 12 months, although the aripiprazole group less so (0.16±4.6 vs. 2.31±6.8 increase in PANSS positive score; p < 0.05).^95^ Between-group changes for negative symptoms were not significant in this study (p = 0.22).

There were no differences between olanzapine and placebo groups for changes in positive symptoms in patients experiencing prodrome (p = 0.44).^86^ Figures 40 and 41 present data on negative (PANNS and SANS) and depression (Hamilton Depression Rating Scale and Montgomery-Asberg Depression Rating Scale) symptoms from the two 12-month RCTs enrolling patients at high-risk for schizophrenia.^86, 93^

Figure 40 SGAs versus placebo for negative symptoms at 12 months in schizophrenia and related psychosis

SD = standard deviation; SGA = second-generation antipsychotic

Figure 40 shows a meta-graph of studies reporting the standard mean difference of 12-month negative symptoms in schizophrenia and related psychosis with use of SGAs versus placebo. Specific to Olanzapine (1 trial, 60 subjects; SMD, 0.08; 95% CrI, −0.43 to 0.59) and Risperidone (1 trial, 87 subjects; SMD, 0.12; 95% CrI, −0.30 to 0.54) no significant difference were found between groups.

Figure 41 SGAs versus placebo for depression symptoms at 12 months in schizophrenia and related psychosis

SD = standard deviation; SGA = second-generation antipsychotic

Figure 41 displays a meta-graph of studies reporting the standard mean difference of 12-month depression syndromes in schizophrenia and related psychosis with use of SGAs versus placebo. Specific to Olanzapine (1 trial, 60 subjects) results non-significantly favored placebo (SMD, 0.07; 95% CrI, −0.44 to 0.59). Results specific to Risperidone (1 trial, 87 subjects) showed non-significant favoring of the SGA versus placebo (SMD, −0.31; 95% CrI, −0.73 to 0.12).

Long-term nonspecific symptoms. Patients maintained on aripiprazole had significantly lower overall schizophrenia symptoms at 1-year than those on placebo (−1.3 vs. 4.8 points on PANSS total; p = 0.06).^95^ Overall relapse rate (CGI-I ≥5 and ≥20% increase in PANSS total) was lower for those maintained on aripiprazole than placebo (19.4% vs. 37.5%; p = 0.0161).^95^ Response and remission rates did not differ between these groups (p = 0.1 and 0.9, respectively).

For 12-month transition to psychosis disorder (Figure 42), olanzapine appeared favorable over placebo (16.1% vs. 37.9% conversion) but the result did not reach statistical significance (p = 0.08).^86^

Figure 42 SGAs versus placebo for transition to psychosis at 12 months in schizophrenia and related psychosis

SGA = second-generation antipsychotic

Figure 42 depicts a meta-graph showing the results of studies comparing SGAs versus placebo for 12-month transition to psychosis in schizophrenia and related psychosis. Specific to Olanzapine (1 trial, 60 subjects), results non-significantly favored Olanzapine over placebo (RR, 0.43; 95% CrI, 0.17 to 1.08). A comparison of Risperidone versus placebo (1 trial, 87 subjects) showed no difference between groups (RR, 1.02; 95% CrI, 0.39 to 2.67).

Long-term global impressions. Maintenance treatment with aripiprazole was not significantly different than with placebo for long-term scores in global impressions of improvement (3.42 vs. 3.92 on CGI-I, respectively; p = 0.08), or changes from baseline in illness severity (0.05 vs. 0.29 on CGI-S; p = 0.23) or global functioning (2.35 vs. −2.25 on C-GAS; p = 0.09).^95^

Patients experiencing prodrome psychosis did not benefit more from olanzapine than from placebo for global impressions of severity (p = 0.51) at 12 months.^86^ Figure 43 shows the results for global impressions of functioning using GAF in schizophrenia prodrome. There was no difference between the SGAs and placebo for this outcome in either RCT.^86, 93^

Figure 43 SGAs versus placebo for 12-month global impressions of functioning in schizophrenia and related psychosis

SGA = second-generation antipsychotic; SD = standard deviation

Figure 43 displays a meta-graph showing the results of studies comparing SGAs versus placebo for 12-month global impressions of functioning in schizophrenia and related psychosis. Results showed no difference in this outcome for Olanzapine (1 trial, 60 subjects; MD, 2.30; 95% CrI, −4.90 to 9.50) and Risperidone (1 trial, 87 subjects; MD, −2.80; 95% CrI, −7.43 to 1.83).

Suicide-related ideations or behaviors. Four short-term RCTs reporting on suicide attempts did not find any differences between groups;^71, 72, 90, 92^ all had either no or one attempt in any group. Three short-term RCTs reported no suicides.^72, 73, 88^ Two RCTs reported on suicide behaviors; no behaviors in either group were reported in the study of olanzapine,^76^ while one patient in each arm exhibited behaviors in the study of aripiprazole.^95^ Suicide ideations were no different between placebo and ziprasidone^71^ or quetiapine^72^ groups; two or fewer patients in either arm had suicide ideations.

Quality of life. Using the Pediatric Quality of Life Enjoyment and Satisfaction Questionnaire; neither low- (p = 0.55) or high-dose (p = 0.26) aripiprazole groups were favorable over placebo for this outcome at 6-weeks.^73^ There was no difference in the Quality of Life Scale scores between risperidone and placebo groups at 12 months for patients experiencing the prodrome phase (p = 0.14).^93^

Caregiver burden/strain. Parents of those in the lower (400 mg/day) and higher (800 mg/day) quetiapine dose groups experienced significantly greater reduction than placebo in scores on the Caregiver Strain Questionnaire (p = 0.008).^72^

### Schizophrenia and Related Psychoses: Within-Study Subgroup Effects

Table 7 summarizes the within-study analysis for subgroups of interest. Four studies examined the impact of age on total PANSS scores,^94^ global clinical judgments rating,^83^ treatment response,^82^ and conversion to psychosis.^86^ Patients experiencing only mild or moderate improvement on the global clinical judgments rating scale on haloperidol tended to be younger than those rated as more improved.^83^ A greater-than–two point difference in change in total PANSS scores was observed between 12-to-14 and 15-to-17 age groups in one study, although it is unclear which group received more benefit.^94^ Age had no impact on response rate or conversion to psychosis. One study found that race (African American) predicted conversion to psychosis.^86^

Table 7 Within-study analyses for subgroups of interest for schizophrenia and related psychoses

First Author, Year Comparison | Type of Analysis | Outcome | Authors’ Conclusions
Savitz, 2015^94^ Paliperidone ER vs aripiprazole | Subgroup analysis by age, previous antipsychotic exposure, illness duration | PANSS | Changes in PANSS total score were comparable regardless of age group, weight category, region, number of previous antipsychotic medications (<3 vs. ≥3) and duration of schizophrenic illness (<3 vs. ≥3 yr), except in the 12 to 14 year age group (between-group difference was >2 points).
Sikich, 2004^82^ Haloperidol vs. olanzapine vs. risperidone | Subgroup analysis by age, cotreatment, treatment history, diagnosis, baseline symptom severity | Response | No significant relationship between response status and age, diagnosis, prior antipsychotic exposure or baseline severity of symptoms. Also, there was no significant difference in response rate between patients treated exclusively with antipsychotic, treated with either concomitant antidepressant or mood stabilizer, or both concomitant antidepressant and mood stabilizer.
Spencer, 1994^83^ Haloperidol vs. placebo | Subgroup analysis by age, age of onset, IQ | Global clinical judgments rating | Patients with only mild or moderate improvement tended to be younger, have earlier onset of psychosis, be diagnosed with schizophrenia at a younger age and have a lower IQ.
Woods, 2003^86^ Olanzapine vs. placebo | Subgroup analysis by age, race, IQ, baseline neuropsychological status | Conversion to psychosis | There was no difference between patients who converted to psychosis and those who did not in age, IQ or global neuropsychological status. Race, poor CPT performance and good digit symbol performance predicted conversion to psychosis.
Woods, 2003^86^ Olanzapine vs. placebo | | Time to progression to psychosis | Baseline neurocognitive status was not a significant predictor of time to progression to psychosis.
Woods, 2003^86^ Olanzapine vs. placebo | Regression analysis by history of psychosis and duration of prodromal symptoms | Neurocognitive performance | Patients with first-episode psychosis were significantly more impaired than patients at-risk for psychosis on CPT, CVLT, digit symbol, working memory and verbal fluency measures. Cognitive performance was not significantly correlated with length of manifestation of prodromal symptoms.

CPT = continuous performance task; CVLT = continuous verbal learning test; IQ = intelligence quotient; PANSS = Positive and Negative Syndrome Scale

Savitz et al.^94^ found no differences between paliperidone and aripiprazole in change in total PANSS scores for groups differing by weight category, previous antipsychotic exposure, or duration of illness. One study investigated the effect of antipsychotic monotherapy compared with treatment with an antipsychotic plus concomitant antidepressant and/or mood stabilizers on response rate.^82^ The study found no significant difference in response rate between subgroups in patients given haloperidol, olanzapine, or risperidone. Woods et al.^86^ analyzed the effect of history of psychosis and duration of prodromal symptoms on neurocognitive performance in olanzapine-treated patients. Patients with first-episode psychosis were significantly more impaired on neurocognitive function test than patients at risk for psychosis.^83^ Two studies found no impact of illness duration on global clinical judgments rating or neurocognitive performance.^86^

### Bipolar Disorder: Overview

Nineteen studies compared SGAs with other drugs of the same class or with placebo in children and adolescents with bipolar disorder.^65, 66, 105–121^ Tables 8 and 9 provide selected information on the characteristics of the individual trials and the one observational study,^107^ respectively. Studies that include both head-to-head and placebo comparisons are listed under the head-to-head category. Head-to-head drug comparisons were made in three studies comparing chlorpromazine with olanzapine,^66^ and risperidone with olanzapine^113^ and quetiapine.^112^ Different doses of the same SGA were compared in five trials.^65, 108, 117–119^ Fourteen RCTs compared one or more doses of an SGA to placebo.^105, 106, 108–111, 114–121^ Most studies had flexible-dosing protocols; three used fixed doses when comparing two or three doses of the same SGA.^65, 108, 119^ Detailed evidence tables are available in Appendix D.

Table 8 Characteristics of trials examining bipolar disorder

First Author, Year Study Design, Duration | Intervention (N Enrolled), Dosage (mg/day) Mean±SD | Age, Mean±SD (Range)/Males (%)/White (%) Comorbidities | Diagnosis Breakdown (n) Quality Rating
FGAs vs SGAs
Conus et al., 2015^66^ RCT, 8wk | G1: Chlorpromazine (41), 185.9±126.7 mg/day G2: Olanzapine (42), 12.2±7.8 mg/day | G1: 22±3 yr/Male: 63.9%/White: NR G2: 21.1±2.7/Male: 71.1%/White: NR | Psychotic features within bipolar I (61) or schizoaffective disorder (22) History of treatment: NR ROB: High (subjective), High (objective)
SGAs vs. SGAs
Findling, 2009^117^ RCT, 4 wk | G1: Aripiprazole (low) (98), range: 2–10 mg/day G2: Aripiprazole (high) (99), range: 2–30 mg/day G3: Placebo (99) | G1: 13.7±2.2 yr/Male: 53%/White: 66% G2: 13.3±2.3 yr/Male: 52%/White: 69% G3: 13.3±2.1 yr/Male: 57%/White: 61% Comorbidities: ADHD (153), DBD (93), psychosis (14) | bipolar I (all), mania (119), mixed (125), unknown (52) ROB: Medium (subjective), Medium (objective)
Findling, 2015b^108^ RCT, 3 wk | G1: Asenapine (104), 2.5 mg/day G2: Asenapine (99), 5 mg/day G3: Asenapine (99), 10 mg/day G4: Placebo (101) | G1: 13.7±2.1 yr/Male: 50%/White: 72.1% G2: 13.8±2.0 yr/Male: 44%/White: 67.7% G3: 13.9±2.1 yr/Male: 58.6%/White: 65.7% G4: 13.7±2.0 yr/Male: 37.6%/White: 67.3% Comorbidities: ADHD (220) | manic (171), mixed (232) ROB: Low (subjective), Low (objective)
Biederman, 2005^113^ RCT, 8 wk | G1: Olanzapine (15), 6.3±2.3 mg/day G2: Risperidone (16), 1.4±0.5 mg/day | G1: 5.0±0.8 yr/Male: 67%/White: 100% G2: 5.3±0.8 yr/Male: 75%/White: 94% Comorbidities: ADHD (19), CD (13), MDD (22) | bipolar I (27), bipolar NOS (4), mania (all) ROB: High (subjective), High (objective)
Pathak, 2013^119^ RCT, 3 wk | G1: Quetiapine, low dose (93), 400 mg/day G2: Quetiapine. high dose (95), 600 mg/day G3: Placebo (89) | G1: 13.1±2.2 yr/Male: 51%/White: 79% G2: 13.2±2.2 yr/Male: 58%/White: 77% G3: 13.3±2.1 yr/Male: 61%/White: 75% Comorbidities: ADHD (124) | bipolar I, manic (272), mixed (5) ROB: High (subjective), High (objective)
Masi, 2015^112^ RCT, 12 wk | G1: Quetiapine (12), 163.3±55.2 mg/day G2: Risperidone (10), 1.90±0.60 mg/day | G1: 14.9±1.1 yr/Male: 71.4%/White: 100% G2: 15.1±1.8 yr/Male: 42.9%/White: 100% Comorbidities: ADHD (5), anxiety disorders (5), substance use disorder (3), eating disorder NOS (2) | hypomanic (all) ROB: High (subjective), High (objective)
Haas, 2009c^118^ RCT, 3 wk | G1: Risperidone (low) (50), range: 0.5–2.5 mg/day G2: Risperidone (high) (61), range: 3–6 mg/day G3: Placebo (58) | G1: NR/Male: 56%/White: 70% G2: NR/Male: 43%/White: 82% G3: NR/Male: 48%/White: 78% Comorbidities: ADHD (85), DBD (101) | bipolar I (all), manic episode (60), mixed episode (109) ROB: High (subjective), High (objective)
DelBello, 2008^65^ RCT, 3 wk | G1: Ziprasidone (low) (15), target: 80 mg/day G2: Ziprasidone (high) (31), target: 160 mg/day | G1: 13.2±2.1 yr/Male: 47%/White: NR G2: 13.8±2.4 yr/Male: 77%/White: NR Comorbidities: NR | bipolar I (all) ROB: High (subjective), High (objective)
SGA vs. Placebo
Tramontina, 2009^121^ RCT, 6 wk | G1: Aripiprazole (18), 13.6±5.4 mg/day G2: Placebo (25) | G1: 11.7±2.7 yr/Male: 33%/White: 83% G2: 12.2±2.8 yr/Male: 56%/White: 96% Comorbidities: ADHD (all), anxiety disorders (21), DBD (35), psychosis (16) | bipolar I (35), bipolar II (8) ROB: Low (subjective), Low (objective)
Findling, 2012b^110^ RCT, 72 wk | G1: Aripiprazole (30), 0.23±0.07 mg/kg/day (at randomization), 0.26±0.11 (end of study) G2: Placebo (30) | G1: 7.1±1.5 yr/Male: 63%/White: NR G2: 6.7±1.7 yr/Male: 77%/White: NR Comorbidities: DBD (11), ADHD (54), any anxiety disorder (2) | bipolar disorder NOS (33), bipolar I disorder (21), cyclothymia (6) ROB: High (subjective), High (objective)
NCT00194012^106^ RCT, 12 wk | G1: Aripiprazole (30), 2–15 mg/day G2: Placebo (29) | G1: 5–17 yr/Male: 66.7%/White: NR G2: 5–17yr/Male: 51.7%/White: NR Comorbidities: NR (ASD & MR exclusion criteria) | bipolar NOS or cyclothymia ROB: High (subjective), High (objective)
Tohen, 2007^120^ RCT, 3 wk | G1: Olanzapine (107), 8.9 mg/day G2: Placebo (54) | G1: 15.1±1.3 yr/Male: 57%/White: 66% G2: 15.4±1.2 yr/Male: 44%/White: 76% Comorbidities: ADHD (58), DBD (49) | bipolar I (all), mixed (86), psychotic features (29), rapid cycling (30) ROB: Medium (subjective), Medium (objective)
DelBello, 2002^115^ RCT, 6 wk | G1: Quetiapine (15), 432 mg/day G2: Placebo (15) | G1: 14.1±2 yr/Male: 53%/White: 80% G2: 14.5±2 yr/Male: 53%/White: 87% Comorbidities: ADHD (18), psychosis (14) | bipolar I (all), mixed episode (23) ROB: Medium (subjective), Medium (objective)
DelBello, 2009^114^ RCT, 8 wk | G1: Quetiapine (17), 403±133 mg/day G2: Placebo (15) | G1: 16.0±2 yr/Male: 29%/White: 82% G2: 15±2 yr/Male: 33%/White: 80% Comorbidities: ADHD (4), anxiety disorder (8), DBD (8), psychosis (3) | bipolar I with depressive episode (32) ROB: High (subjective), High (objective)
Findling, 2014a^109^ RCT, 8 wk | G1: Quetiapine (92), mean modal dose: 204.9 mg/day G2: Placebo (100) | G1: 13.9±2.2 yr/Male: 48.9%/White: 70.7% G2: 14.0±2.1 yr/Male: 52%/White: 60% Comorbidities: ADHD (84) | bipolar I or II with depression ROB: High (subjective), High (objective)
Kowatch, 2015^111^ RCT, 6 wk | G1: Risperidone (18), 0.5 (0.5–0.75) mg/day G2: Placebo (7) | G1: 5.31±1.3 yr/Male: 61%/White: 61% G2: 5.19±1.0 yr/Male: 71%/White: 71% Comorbidities G1/G2: ADHD (37/15.2%), ODD (4.3/0%), GAD (8.7/6.5%) | manic, hypomanic, mixed ROB: Medium (subjective), Medium (objective)
Findling, 2013b^116^ RCT, 4 wk | G1: Ziprasidone (149), target: 60–80 mg/day (<45 kg), 120–160 mg/day (>45 kg) G2: Placebo (88) | G1: 13.6 yr/Male: NR/White: NR G2: 13.7 yr/Male: NR/White: NR Comorbidities: NR | bipolar I (237) ROB: High (subjective), High (objective)
Schneider, 2012^105^ RCT, 4 wk | G1: Ziprasidone (14), 20 mg/day G2: Placebo (9) | G1: 14.7±2.3 yr/Male: 64%/White: 86% G2: 14.5±2.2 yr/Male: 22%/White: 89% Comorbidities: ADHD (10) | bipolar I mixed (18), manic (NR) ROB: High (subjective), High (objective)

ADHD = attention deficit hyperactivity disorder; ASD = autism spectrum disorders; DBD = disruptive behavior disorder; FGA = first-generation antipsychotic; G = group; GAD = general anxiety disorder; KQ = key question; mg = milligram; mo = month; N = number; NOS = not otherwise specified; NR = not reported; OCD = obsessive-compulsive disorder; ODD = oppositional defiant disorder; PDD = pervasive developmental disorder; RCT = randomized controlled trial; ROB = risk of bias; SD = standard deviation; SGA = second-generation antipsychotic; wk = week; yr = year

Table 9 Characteristics of observational studies examining bipolar disorder

First Author, Year Study Design, Duration | Intervention (N Enrolled), Dosage (mg/day) Mean±SD | Age, Mean±SD (Range)/Males (%)/White (%) Comorbidities | Diagnosis Breakdown (n) Quality Rating
SGAs vs. SGAs
Oh, 2013^107^ Retrospective cohort, 7–8 mo | G1: Aripiprazole (62), 9.58±5.38 mg/day G2: Others (65), 1.46±1.08 mg/day (risperidone), 207.46±200.53 mg/day (quetiapine), 4.50±2.12 mg/day (paliperidone) | G1: 13.16±2.80 yr/Male: 66.1%/White: NR G2: 11.46±3.95 yr/Male: 76.9%/White: NR Comorbidities: ADHD (50), tic related disorders (17), conduct disorders and ODD (5), autism spectrum disorder (12) | Bipolar I, II, NOS (NR) 6/8 stars

ADHD = attention deficit hyperactivity disorder; G = group; mg = milligram; mo = month; N = number; NOS = not otherwise specified; NR = not reported; ODD = oppositional defiant disorder; SD = standard deviation; SGA = second-generation antipsychotic; wk = week; yr = year

The average age of patients was 12.8 years. Both sexes were equally represented across the studies (56% male). The majority of patients (range 65–100%) reported a White race/ethnicity. Diagnosis of bipolar disorder was established using the DSM–IV or DSM–IV–TR. Most studies enrolled patients having bipolar I disorder. Three studies had a mixture of bipolar I and bipolar II disorder,^107, 109, 121^ and three others included patients with bipolar disorder not-otherwise-specified (NOS).^107, 110, 113^ One study only enrolled patients with bipolar NOS or cyclothymia,^106^ and another only enrolled patients with psychotic features.^66^ Most studies focused on treatment for mania or mixed phases of bipolar disorder; two studies focused on patients having depressive episodes within bipolar I or II disorder.^109, 114^ As noted earlier, the diagnosis of bipolar disorder in children is controversial, particularly in young children (e.g., preschoolers in Biederman et al.^113^). A majority of studies enrolled many (> 40%) children with secondary diagnoses, including ADHD; disruptive, impulse-control, or conduct disorders; and/or anxiety disorders. All of the patients in one study had comorbid ADHD.^121^ Several studies included patients who experienced psychoses.

Sixteen of the trials had followup periods ranging from 3 to 12 weeks. One trial had a controlled extension phase of 30 weeks,^117^ one trial had a placebo-controlled maintenance treatment duration of 72 weeks,^110^ and the observational study reviewed charts for between 7 to 8 months.^107^ Sixty-seven percent of RCTs had high ROB; the most common source of potential bias was incomplete outcome data although some studies^65, 66 112, 113^ did not blind participants or providers. The observational study was of high quality (6 of 8 stars).^107^

### Bipolar Disorder: Intermediate Outcomes

Sixteen RCTs reported on intermediate outcomes for treating bipolar disorder. A summary of the key findings is provided below; some observations related to possible subgroup effects are provided for SGA-placebo comparisons. Table 10 contains the findings and SOE ratings for the key outcomes assessed as having at least low SOE; the reason for each SOE decision is included in the table footnotes. The remainder of this section provides a detailed analysis of the findings by comparison and outcome category.

Table 10 Strength of evidence for bipolar disorder: Key intermediate outcomes having at least low strength of evidence

Comparison | Outcome (N Studies; N Patients) | Findings,^a^ Studies, Tool With Range of Values, if Applicable | Strength of Evidence; Conclusions
Asenapine high (10 mg/day) vs. low (5 mg/day) dose | Manic symptoms (1, 199) | MD, −2.80; 95% CI −0.64 to −4.96 (YMRS; range 0–60)^108^ | Low; High-dose asenapine may decrease slightly manic symptoms
Asenapine high (10 mg/day) vs. low (5 mg/day) dose | Global impressions of severity (1, 199) | MD, −0.10, 95% CI −0.29 to 0.49^108^ | Low; may make little or no difference
Asenapine high (10 mg/day) vs. low (5 mg/day) dose | Depression (1, 199) | MD, 0.80; 95% CI −1.87 to 3.47 (CDRS; range 0–113)^108^ | Low; may make little or no difference
SGAs vs. placebo | Manic symptoms (11, 1639) | MD, −6.42; 95% CrI, −7.88 to −5.26 (YMRS; range 0–60)^106, 108, 111, 114–121^ | Moderate; SGAs probably decrease^b^
SGAs vs. placebo | Depression symptoms (9, 1622) | MD, −1.65; 95% CrI, −2.78 to −0.48 (CDRS; range 0–113)^108, 109, 111, 114, 116, 117, 119–121^ | Moderate; SGAs probably decrease slightly^b^
SGAs vs. placebo | Response (10, 1664) (Manic/mixed phases)^c^ | RR, 1.97; 95% CrI, 1.66 to 2.34 (40–50% reduction in YMRS from baseline) ^105, 108, 111, 115–121^ | Moderate; SGAs probably increase for manic/mixed phases^b^
SGAs vs. placebo | Remission (5, 944) (Manic/Mixed phases)^c^ | RR, 2.84; 95% CrI, 1.67 to 5.55^117–121^ | Moderate; SGAs probably increase for manic/mixed phases^b^
SGAs vs. placebo | Global impressions of severity using CGI-S^d^ (9, 1778) | MD, −0.65; 95% CI, −0.80 to −0.49^108, 109, 114, 116–121^ | Moderate; SGAs probably improve slightly^b^
SGAs vs. placebo | Global impressions of functioning (4, 1188) | MD, 6.64; 95% CrI, 2.45 to 10.95 (C-GAS; range 1–100)^108, 116, 117, 119^ | Moderate; SGAs probably improve slightly^b^
Aripiprazole vs. placebo | Manic symptoms (3, 387) | MD, −7.08; 95% CrI, −10.96 to −3.24 (YMRS; range 0–60)^106, 117, 121^ | Moderate; Aripiprazole probably decreases^b^
Aripiprazole vs. placebo | Depression symptoms (2, 311) | 1 RCT: MD, −1.74; 95% CI, −3.92 to 0.44^117^ 1 RCT: MD, −2.29; 95% CI, −10.62 to 6.04^121^ (CDRS-R; range 17–113) | Low; Aripiprazole may make little or no difference ^e^
Aripiprazole vs. placebo | Response rates (2, 311) | 1 RCT: RR, 2.11; 95% CI, 1.47 to 3.02^117^ 1 RCT: RR, 1.71; 95% CI, 1.13 to 2.58^121^ | Moderate; Aripiprazole probably increases^b^
Aripiprazole vs. placebo | Remission (2, 311) | 1 RCT: RR, 7.09; 95% CI, 2.96 to 16.99^117^ 1 RCT: RR, 2.26; 95% CI, 1.19 to 4.28^121^ | Moderate; Aripiprazole probably increases^b^
Aripiprazole vs. placebo | Global impressions of severity using CGI-S (2, 328) | 1 RCT: MD, −1.00; 95% CI, −1.34 to −0.67^117^ 1 RCT: MD, −0.41; 95% CI, −0.80 to −0.02^121^ | Moderate; Aripiprazole probably improves slightly^b^
Quetiapine vs. placebo | Manic symptoms (3, 339) | MD, −5.34; 95% CrI, −9.92 to −0.44 (YMRS; range 0–60)^114, 115, 119^ | Moderate; Quetiapine probably decreases ^b^
Quetiapine vs. placebo | Depression symptoms (3, 501) | MD, −1.87; 95% CrI, −4.71 to 1.11 (CDRS-R; range 17–113)^109, 114, 119^ | Moderate; Quetiapine probably makes little or no difference ^b^
Quetiapine vs. placebo | Response (2, 307) (Manic/mixed) | 1 RCT: RR, 1.36; 95% CI, 0.97 to 2.72^115^ 1 RCT: RR, 1.97; 95% CI, 1.38 to 2.81^119^ | Low; Quetiapine may make little or no difference ^e^

CDRS-R = Children’s Depression Rating Scale-Revised; C-GAS = Global Assessment Scale for Children; CGI-S = Clinical Global Impressions of Severity; CrI = credible interval (used with Bayesian meta-analysis); MD = mean difference; N = number; RCT: randomized controlled trial; RR = risk ratio; SGA = second-generation antipsychotics; YMRS = Young Mania Rating Scale

a When the findings are not representative of the total number of studies identified in the outcome column, we included the number of studies for each finding; we did not pool data from 1 or 2 studies so these results are always presented separately. All values except Response, Remission, and Global Impressions of Functioning are favorable for the SGA when there is a negative effect estimate; the larger the magnitude of the number the larger the effect.

b Downgraded for ROB.

c When two studies examining the depressive phase were included the heterogeneity has substantial.

d CGI-S and CGI-I scores range from 0–6.

e Downgraded for ROB and imprecision due to CI including clinically relevant benefit for SGAs.

#### Key Points

- Chlorpromazine versus olanzapine:^66^ The differences between these two antipsychotics are not known for symptoms of mania, depression, or psychosis, or for response, remission, or global impressions of severtity.
- Risperidone versus olanzapine^113^ and quetiapine^112^: The effects between risperidone and olanzapine are not known for manic or depression symptoms. Comparative effects of quetiapine and risperidone are not known for outcomes of anxiety, manic or depression symptoms, or global impressions of severity or functioning.
- SGAs—Dose comparisons (aripiprazole,^117^ asenapine,^108^ quetiapine,^119^ risperidone,^118^ ziprasidone^65^): There may be a slightly greater reduction in manic symptoms from high- (10mg/day) versus low-dose (5 mg/day) asenapine; dose of asenapine may make little or no difference for global impressions of severity or for depression. The effects are not known for comparisons between different doses of other SGAs for manic symptoms, remission and response rates, depression, global impressions of severity, or global functioning.
- SGAs versus placebo (aripiprazole,^106, 117, 121^ asenapine,^108^ olanzapine,^120^ quetiapine,^109, 114, 115, 119, 120^ risperidone,^111, 118^ ziprasidone^105, 116^): SGAs probably decrease manic symptoms and decrease slightly depression symptoms. They probably increase response and remission rates for patients experiencing manic/mixed phases; clinical and statistical heterogeneity was introduced when including two RCTs^109, 114^ examining quetiapine for patients with depressive episodes. SGAs likely improve symptom severity and global functioning slightly. When examining individual SGAs versus placebo, the findings for aripiprazole were similar to those across all SGAs, with the exception of depression symptoms where use of this SGA may make little or no difference. Quetiapine probably reduces manic symptoms, likely makes little or no difference for depression symptoms, and may make no difference for response in studies of patients experiencing manic/mixed episodes; the results of little or no difference for response rates (often focused on manic symptoms) were imprecise showing that many patients may have clinically relevant response. The effects of quetiapine versus placebo for remission rates and for global impressions of severity are not known. Observations on between-study subgroup effects: (a) two RCTs focused on patients experiencing depressive episodes,^109, 114^ for whom it appears the efficacy of SGAs for response and remission rates are lower; (b) a study^106^ enrolling patients with prodromal bipolar disorder reported similar efficacy to the other studies of patients with manic symptoms; and (c) a study exclusively enrolling patients having comorbid ADHD^121^ did not appear to differ in effect for several outcomes to other similar studies assessing SGAs in manic or mixed episodes.

#### Detailed Analysis

##### FGAs Versus SGAs

One RCT compared olanzapine with chlorpromazine as adjunct treatment to lithium for intermediate outcomes in first episode psychotic mania. Eighty-three patients (average age 21.5 years) with either bipolar I or schizoaffective disorder were treated for 8 weeks. Patients taking olanzapine were more likely to achieve remission of mania (YMRS score < 12; p = 0.032) at 8 weeks. No significant differences were found for changes in manic or depressive symptoms, reponse (p = 0.121) rates, severity of illness, or positive psychotic symptoms at 8 weeks.^66^

##### SGAs Versus SGAs

Seven RCTs compared either different SGAs^112, 113^ or different doses of the same SGA.^65, 108, 117–119^

Olanzapine versus risperidone. An 8-week RCT compared olanzapine with risperidone in children ages 4 to 6.^113^ Risperdone lowered manic symptoms to a greater extent (6.7 points on the Young Mania Rating Scale [YMRS]; p = 0.04) than olanzapine. The numerical values favored risperidone for change in depression (4.4 points greater reduction on Children’s Depression Rating Scale-Revised [CDRS-R]) but the difference was not significant (p > 0.30).

Quetiapine versus risperidone. A 12-week RCT compared quetiapine with risperidone in treatment naïve adolescents with bipolar II disorder comorbid with conduct disorder.^112^ All outcomes improved for both groups at study endpoint (p < 0.001 for time effects), although there was similar efficacy between groups in manic symptoms (p = 0.34), depression (p = 0.24), aggression (p = 0.62), global clinical severity (p = 0.58), and functional impairment (p = 0.06). Quetiapine was favored for reducing anxiety symptoms (p = 0.03). Responder status was similar between groups (50 and 60 percent for quetiapine and risperidone).

Aripiprazole–Low- versus high-dose. A 4-week RCT randomized 296 children ages 10 to 17 to two doses of aripiprazole (10 mg/day and 30 mg/day) and placebo.^117^ Both dosing groups significantly improved on most outcomes compared with placebo. No significant differences were observed between the two aripiprazole doses for manic symptoms (p = 0.07; high-dose numerically favorable), depression (p = 0.38), or global impression of functioning (p = 0.22). Remission and response rates were higher for the high-dose (47.5% and 63.6%) versus low-dose (25% and 44.8%) group (p = 0.009).

Asenapine-Low- versus medium- versus high-dose. A 3-week placebo-controlled RCT compared three doses (2.5, 5, and 10 mg twice daily) of asenapine.^108^ All three doses offered significant improvement over placebo for manic symptoms, response rates, and global impressions of severity and functioning. The results suggest a dose-response relationship for the outcomes of manic symptoms and response rates (both related to YMRS scores; p values < 0.5, < 0.001, and < 0.0001, respectively), although not for depression or for global impressions of severity or functioning. Only the 10 mg twice daily group was favored over placebo for depression scores on the CDRS.

Quetiapine–Low- versus high-dose. A 3-week placebo-controlled RCT compared the efficacy of low-dose (400 mg/day) and high-dose (600 mg/day) quetiapine.^119^ No significant differences were observed between the two quetiapine dose regimens for manic symptoms (p = 0.16), depression (p = 0.39), response or remission (p > 0.4), or global impressions of severity or functioning (p = 0.51). Both groups showed high medication adherence.

Risperidone–Low- versus high-dose. A 3-week placebo-controlled RCT compared the effectiveness of low-dose (0.5–2.5 mg/day) and high-dose (3–6 mg/day) risperidone.^118^ The following outcomes showed no significant differences between the low- and high-dose groups: mania (p = 0.30), time to onset of improvement of mania, response rates (i.e., >50% reduction in YMRS), overall psychiatric symptoms (p = 0.55), and global clinical impressions of severity (p = 0.40).

Ziprasidone–Low- versus high-dose. Children ages 10 to 17 years with bipolar disorder or schizophrenia were randomized to low-dose (80 mg/day) and high-dose (160 mg/day) ziprasidone in a 3-week RCT.^65^ Separate analyses were provided for patients with bipolar disorder (N = 46). No significant differences were found between the two doses for global impressions of severity (p = 0.65) or manic symptoms (p = 0.21).

##### SGAs Versus Placebo

Thirteen RCTs compared various SGAs with placebo for intermediate outcomes in bipolar disorder: aripiprazole,^106, 117, 121^ asenapine,^108^ olanzapine,^120^ quetiapine,^109, 114, 115, 119^ risperidone,^111, 118^ and ziprasidone.^105, 116^ Average treatment duration was 5.5 weeks (range 3–12 weeks). The average age of patients was 13.1 years, which included one study of children ages 3 to 7.^111^ A total of 1,958 patients were enrolled in the trials. Most patients had a diagnosis of bipolar I disorder with the exception of three trials: two trials had approximately 20 percent patients with bipolar II,^109, 121^ and one trial enrolled patients only with bipolar NOS or cyclothymia (“prodromal”).^106^ The most clinical heterogeneity was suspected from two RCTs focusing on treatment of depressive episodes.^108, 114^

###### Meta-Analysis for SGAs Versus Placebo in Bipolar Disorder

Meta-analyses were conducted to compare SGAs with placebo for the short-term core symptoms of mania (YMRS) and depression (CDRS-R). They were also conducted for short-term nonspecific symptoms of response rate, remission, and discontinuation for lack of efficacy, and for global impressions of severity (CGI-Bipolar for severity) and functioning (C-GAS). To examine any effects based on clinical heterogeneity, sensitivity analyses were conducted by removing the studies examining depressive episodes.^109, 114^

Short-term core symptoms. Eleven RCTs^106, 108, 111, 114–121^ evaluated the efficacy of SGAs versus placebo for manic symptoms, as measured by the YMRS (Figure 44). The results favored the SGAs (MD, −6.42; 95% CrI, −7.88 to −5.26; I^2^ = 34%). Sensitivity analysis was conducted by removing the DelBello et al. study of patients experiencing depressive episodes;^114^ results were similar (MD, −6.60; 95% CrI, −8.14 to −5.50; I^2^ = 21%).

Figure 44 SGAs versus placebo for manic symptoms using YMRS in bipolar disorder

CrI = credible interval; MD = mean difference; SD = standard deviation; SGA = second-generation antipsychotic

Figure 44 displays the results of a meta-analysis of studies reporting the mean difference of manic symptoms using YMRS in bipolar disorder with use of SGAs versus placebo. Our meta-analysis (11 trials, 1532 subjects) showed SGAs as more efficacious in treating manic symptoms than placebo (MD, −6.42; 95% CrI, −7.88 to −5.26; I2=34%). Specific to Aripiprazole (3 trials, 398 subjects) results showed a significant difference favoring the SGA versus placebo (MD, −7.08; 95% CrI, −10.96 to −3.24; I2=0%). Results for Quetiapine (3 trials, 339 subjects;) were similar (MD, −5.34; 95% CrI, −9.92 to −0.44; I2=47%).

Meta-analysis of three studies^106, 117, 121^ comparing aripiprazole with placebo showed a significant difference favoring aripiprazole (MD, −7.08; 95% CrI, −10.96 to −3.24); there was no evidence of statistical heterogeneity (I^2^ = 0%) although the unpublished study examined patients with prodromal bipolar disorder (NCT00194012^106^) The three studies^114, 115, 119^ of quetiapine were also meta-analyzed (MD, −5.34; 95% CrI, −9.92 to −0.44; I^2^ = 47%), with results showing moderate statistical heterogeneity which may be related to the relatively lower extent of baseline mania symptoms in the 2009 study by DelBello of depression episodes.

Nine RCTs^108, 109, 111, 114, 116, 117, 119–121^ compared various SGAs versus placebo for depression symptoms using the CDRS-R (Figure 45). Only one study found a statistically significant difference, favoring asenapine over placebo.^108^ Results of the meta-analysis across all studies found a significant difference favoring SGAs (MD, −1.65; 95% CrI, −2.78 to −0.48; I^2^ = 0%). Because of the lack of any statistical heterogeneity and focus on depression symptoms, we did not undertake sensitivity analysis by removing the two studies (DelBello 2009 and Findling 2014a) with patients having depression episodes.^109, 114^ Meta-analysis of data from three RCTs^109, 114, 119^ found no difference between quetiapine and placebo for depression symptoms (MD, −1.87; 95% CrI, −4.71 to 1.11; I^2^ = 0%). Neither of the two studies^109, 114^ focusing on the depressive phase found quetiapine beneficial for these symptoms.

Figure 45 SGAs versus placebo for depression using CDRS-R in bipolar disorder

CDRS-R = Children’s Depression Rating Scale-Revised; CrI = credible interval; MD = mean difference; SD = standard deviation; SGA = second-generation antipsychotic

Figure 45 displays a meta-analysis of studies reporting the mean difference of depression symptoms using CDRS-R in bipolar disorder with use of SGAs versus placebo. Our meta-analysis (9 trials, 1466 subjects) showed a significant difference favoring SGAs versus placebo for depression symptoms (MD, −1.65; 95% CrI, −2.78 to −0.49; I2=0%). A meta-analysis specific to Quetiapine (3 trials, 501 subjects) found no difference between Quetiapine and placebo for depression symptoms (MD, −1.87; 95% CrI, −4.71 to 1.11; I2=0%).

Short-term nonspecific symptoms. Twelve studies reported on response rates for comparisons of SGAs with placebo (Figure 46).^108, 109, 114–121^ Apart from the studies (DelBello 2009 and Findling 2014a) examining depression (using CDRS-R scores for response), the response rates were based on 40 to 50 percent reduction in YMRS at endpoint. Results favored SGAs for higher response, showing a RR of 1.73 (95% CrI, 1.41 to 2.18). Sensitivity analysis removing the studies of depression resulted in a higher RR of 1.97 (95% CrI, 1.66 to 2.34) and reduced the heterogeneity (I^2^ = 0% from 62%).

Figure 46 SGAs versus placebo for response rates in bipolar disorder

CrI = credible interval; RR = risk ratio; SGA = second-generation antipsychotic

Figure 46 displays a meta-analysis of studies comparing SGAs versus placebo for response rates in bipolar disorder. Our meta-analysis (12 trials, 1688 subjects) showed a higher response rate for SGAs versus placebo (RR, 1.97; 95% CrI, 1.66 to 2.34; I2=0%).

Rates of remission were reported by seven trials (Figure 47).^109, 114, 117–121^ Higher remission rates were found for patients taking SGAs compared with placebo (RR, 2.22; 95% CrI, 1.26 to 4.12). Removing the studies of patients experiencing depression found higher rates of remission for patients taking SGAs for manic/mixed episodes (RR, 2.84; 95% CrI, 1.67 to 5.55); the statistical heterogeneity (I^2^) was reduced from 72 percent to 42 percent.

Figure 47 SGAs versus placebo for rates of remission in bipolar disorder

CrI = credible interval; RR = risk ratio; SGA = second-generation antipsychotic

Figure 47 displays a meta-analysis of studies comparing SGAs versus placebo for rates of remission in bipolar disorder. Our meta-analysis (7 trials, 1170 subjects) showed significantly higher remission rates for SGAs versus placebo (RR, 2.22; 95% CrI, 1.26 to 4.12; I2=72%). Results specific to patients taking SGAs versus placebo for manic/mixed episodes (RR 2.84; 95% CrI, 1.67 to 5.55; 42%) were similar.

Nine studies provided data for meta-analysis of discontinuation due to lack of efficacy (Figure 48). Results favored SGAs over placebo (RR, 0.37; 95% CrI, 0.23 to 0.61; I^2^ = 0%); there was no effect from removing the DelBello^114^ and Findling^109^ studies. Individual meta-analysis for aripiprazole^106, 117, 121^ and quetiapine^109, 114, 115^ failed to show significant benefit for these SGAs (aripiprazole: RR, 0.36; 95% CrI, 0.09 to 1.35, and quetiapine: RR, 0.55; 95% CrI, 0.13 to 2.65).

Figure 48 SGAs versus placebo for discontinuation due to lack of efficacy in bipolar disorder

CrI = credible interval; RR = risk ratio; SGA = second-generation antipsychotic

Figure 48 shows the results of a meta-analysis of studies comparing SGAs versus placebo for discontinuation due to lack of efficacy in bipolar disorder. Our meta-analysis (9 trials, 1253 subjects) showed significant favor of SGA versus placebo for this outcome (RR, 0.37; 95% CrI, 0.23 to 0.61; I2=0%). Specific meta-analyses for Aripirazole (3 trials, 398 subjects; RR, 0.36; 95% CrI, 0.09 to 1.35; I2=0%) and Quetiapine (3 trials, 254 subjects; RR, 0.55; 95% CrI, 0.13 to 2.65; I2=0%) failed to show a significant benefit with use of these individual SGAs versus placebo.

Short-term global impressions. Nine RCTs^108, 109, 114, 116–121^ provided data for a meta-analysis of the efficacy of SGAs versus placebo for global impressions of severity (Figure 49). Two studies used the CGI–S,^116, 121^ and seven studies used the CGI–Bipolar Version for Severity. The combined estimate favored SGAs (MD, −0.65; 95% CI, −0.80 to −0.49; I^2^ = 24%). Removing the two studies enrolling patients in the depressive episode^109, 114^ did not affect the results (MD, −0.68; 95% CrI, −0.86 to −0.52; I^2^ = 20%).

Figure 49 SGAs versus placebo for global impression of severity using CGI-S/CGI-BP in bipolar disorder

CGI-S = Clinical Global Impressions of Severity; CGI-BP = Clinical Global Impressions for Bipolar Illness; CrI = credible interval; MD = mean difference; SD = standard deviation; SGA = second-generation antipsychotic

Figure 49 displays a meta-analysis of studies reporting the mean difference of global impression of severity using CGI-S/CGI-BP in bipolar disorder. Our meta-analysis (9 trials, 1610 subjects) showed SGAs were favorable compared with placebo (MD, −0.65; 95% CrI, −0.80 to −0.49; I2=24%).

Four studies provided data for SGAs versus placebo on global impressions of functioning, measured using the C-GAS (Figure 50).^108, 116, 117, 119^ The SGAs were favorable over placebo for improving overall functioning (MD, 6.64; 95% CrI, 2.45 to 10.95). There was moderate statistical heterogeneity (I^2^ = 61%) which may in part relate to the higher relative dose of SGA used in one of the aripiprazole groups in the Findling 2009 study.^117^

Figure 50 SGAs versus placebo for global impression of functioning using C-GAS in bipolar disorder

C-GAS = Children’s Global Assessment Scale; CrI = credible interval; MD = mean difference; SD = standard deviation; SGA = second-generation antipsychotic

Figure 50 displays a meta-analysis of studies comparing use of SGAs versus placebo for global impression of functioning using C-GAS in bipolar disorder. Our meta-analysis (4 trials, 1013 subjects) showed SGAs were favorable for improving overall functioning versus placebo (MD, 6.64; 95% CrI, 2.34 to 10.95; I2=61%).

Medication adherence. Ten RCTs contributed to a meta-analysis comparing poor adherence rates (often discontinuation for poor treatment compliance) for SGAs versus placebo (Figure 51).^105, 106, 108–110, 115, 117–118, 121^ The only drug that approached statistical significance for better adherence over placebo was asenapine;^108^ the relatively short (3-week) treatment duration may have influenced these results. The pooled results for all comparisons showed no significant difference between groups (RR, 0.96; 95% CrI, 0.48 to 1.96). Meta-analysis was conducted for aripiprazole (RR, 1.51; 95% CrI, 0.41 to 5.47)^106, 110, 117, 121^ and quetiapine (RR, 1.04; 95% CrI, 0.25 to 5.58),^109, 114, 119^ with similar results of no difference.

Figure 51 SGAs versus placebo for poor medication compliance in bipolar disorder

CrI = credible interval; MD = mean difference; SGA = second-generation antipsychotic

Figure 51 shows a meta-analysis of studies comparing use of SGAs and use of placebo for poor medication compliance in bipolar disorder. Our meta-analysis (10 trials, 1352 subjects) showed no significant difference in compliance between groups (RR, 0.96; 95% CrI, 0.48 to 1.96; I2=9%). Results specific to Aripiprazole (4 trials, 453 subjects; RR, 1.51; 95% CrI, 0.41 to 5.47; I2=0%) and Quetiapine (3 trials, 499 subjects) were similar.

Lifestyle behaviors. Data provided by five RCTs^114, 117–119, 121^ on increases in appetite as reported by patients found no difference between SGAs and placebo (RR, 1.64; 95% CrI, 0.62 to 7.18) (Figure 52). Two studies having treatment durations of 6 months or longer found similar results. In one study,^117^ 6 versus 0 percent (p = 0.13) of patients taking aripiprazole or placebo, respectively, reported increased appetite after 12 months of treatment. In the other study,^110^ of 12-month placebo-controlled aripiprazole maintenance treatment, 30 versus 43 percent taking aripiprazole or placebo reported increases.

Figure 52 SGAs versus placebo for increases in appetite in bipolar disorder

CrI = credible interval; RR = risk ratio; SGA = second-generation antipsychotic

Figure 52 displays a meta-analysis of studies comparing SGAs versus placebo for increases in appetite in bipolar disorder. Our meta-analysis (5 trials, 817 subjects) showed no difference between groups (RR, 1.64; 95% CrI, 0.62 to 7.18; I2=41%).

###### Additional Findings

Few studies reported on psychotic symptoms, despite many enrolling patients with this symptomatology; one study on quetiapine reported no between-group differences (p = 0.8) in positive symptoms using the PANSS. The incidence of switch to depression (CGI depression score ≤3 at baseline and ≥4 points at any time during the double-blind phase) did not differ significantly between olanzapine and placebo.^120^ A single study favored aripiprazole over placebo on the General Behavior Inventory (p < 0.0001).^117^ Patients using olanzapine showed significantly greater (p = 0.002) improvement in aggression on the OAS than patients on placebo.^120^ There was no significant difference (p = 0.76) between quetiapine and placebo groups on the Hamilton Anxiety Rating Scale in another study.^114^ Risperidone was favored (p = 0.004) over placebo for general psychiatric symptoms on the BPRS.^118^ Taking ziprasidone improved global impressions on the CGI-I in one study (MD, −0.76; p = 0.002).^116^

###### Observations on Between-Study Subgroup Effects

The trials examining SGAs versus placebo were fairly similar in terms of patient populations, protocols, and duration. There was some heterogeneity in terms of phase of illness (e.g., manic or mixed vs. depressive) and relative number of patients having comorbidities. Apart from the studies examining depressive episodes which marginally impacted (reduced) effects on response and remission rates,^109, 114^ the study enrolling patients with prodromal bipolar disorder^106^ reported similar efficacy to the other studies of patients with manic symptoms. The study by Tramontina et al.^121^ exclusively enrolling patients having comorbid ADHD did not appear to differ in effect for several outcomes to other similar studies assessing SGAs in manic or mixed episodes. These authors also stated that there were no between group differences in ADHD symptoms.

### Bipolar Disorder: Effectiveness Outcomes

Eleven studies reported on effectiveness outcomes when treating children for bipolar disorder. With the exception of the observational study comparing various SGAs,^107^ all studies reported on SGAs versus placebo. A summary of the findings on key outcomes by comparison is provided below. Table 11 contains the findings and SOE grades the key outcomes assessed as having at least low SOE; the reason for each SOE decision is included in the table footnotes. A detailed analysis for all relevant outcomes follows.

Table 11 Strength of evidence for bipolar disorder: Key effectiveness outcomes having at least low strength of evidence

Comparison | Outcome (N Studies; N Patients) | Findings^a^ | Strength of Evidence; Conclusion
SGAs vs. placebo | Suicide ideation (8, 1782) | RR, 1.12; 95% CrI, 0.58 to 2.26^108, 109, 116–121^ | Low; may make little or no difference ^b^
SGAs vs. placebo | Suicide attempts (6, 1285) | RR, 1.71; 95% CrI, 0.39 to 7.38^108, 114, 116, 118–120^ | Low; may make little or no difference ^b^

CrI = credible interval (used with Bayesian meta-analysis); RR = risk ratio; SGA = second-generation antipsychotics.

a Positive RR represents benefit for placebo group.

b Downgraded for ROB and imprecision because CrI included values favoring either group to clinically meaningful extent (i.e., RR ≤0.75 or ≥1.25).

#### Key Points

- SGAs versus SGAs (one retrospective cohort^107^): The comparative effectiveness of risperidone, quetiapine, and aripiprazole for global impressions of improvement or severity after 4- to 6-month followup are not known.
- SGAs versus placebo (10 RCTs: aripiprazole,^110, 117, 121^ asenapine,^108^ olanzapine,^118^ quetiapine,^109, 114, 119^ risperidone,^118^ ziprasidone^116^): There may be little or no difference between SGAs and placebo for suicide ideations and attempts. Studies examining long-term aripiprazole for acute and maintenance treatment with placebo reported on outcomes of manic and depression symptoms, global impressions of severity and functioning, response, and quality of life; all effects are considered unknown. Effects of ziprasidone on speed of processing are unknown, nor are the effects of olanzapine for psychosocial, behavior, family activities, and mental health scores. Besides suicide attempts and ideations, conclusions were of unknown effect (insufficient SOE) due to ROB and inconsistency (or unknown consistency) and/or imprecision.

#### Detailed Analysis

##### Description of Long-Term Studies

Aripiprazole versus risperidone, quetiapine, and paliperidone. A retrospective cohort study examined charts of 125 outpatients with bipolar I, II or NOS ages 4 to 18 years attending a psychiatric clinic over a period of five visits (7.9±5.3 months).^107^ Aripiprazole, risperidone, and quetiapine were administered to 62, 52, and 11 patients, respectively; the dose of aripiprazole was higher in terms of chloropromazine-equivalent doses.

Aripiprazole–Low- versus high-dose. A 4-week RCT (N = 296) comparing two doses of aripiprazole (10 mg/day and 30 mg/day) and placebo added a 26-week extension phase for acute treatment completers (n = 210 although results for intention-to-treat of whole sample).^117^

Aripiprazole versus placebo. A 72-week RCT (N = 60) was undertaken to compare aripiprazole with placebo for maintenance in children ages 4 to 9 with bipolar disorder I, II, NOS, or cylcothymia and stable for >12 weeks on aripiprazole (6.4±2.1 mg/day).^110^

##### Results on Effectiveness Outcomes From Short- and Long-term Studies

Long-term core symptoms. At 30 weeks, groups receiving low and high doses of aripiprazole had lower YMRS scores than placebo when considering the whole study population or only those in the extension phase (6.5 and 7 point reductions, respectively; p < 0.001);^117^ very similar responses were found between doses. Neither dose of aripiprazole helped reduce depression symptoms compared with placebo. In the 72-week maintenance study of aripiprazole versus placebo, no significant between-group treatment effects were found for core symptoms of mania (YMRS) or depression (CDRS) (p > 0.05).^110^

Long-term nonspecific symptoms. Most patients discontinued treatment from the aripiprazole and placebo arms of the 72-week maintenance study (73% vs. 97%; p = 0.06).^110^ Time until discontinuation as a result of a mood event was significantly longer for the aripiprazole group (25.93±31.8 vs. 3.10±1.0 weeks; p = 0.005). In the 30-week study of Findling et al.,^117^ more patients were discontinued from the placebo (48.4%) compared with aripiprazole groups (22.7 and 14.1 for low- and high-dose groups) for lack of efficacy. Time to discontinuation in this study significantly favored aripiprazole (low-dose p < 0.001; high-dose p < 0.05), but the results were not specific to lack of efficacy.

Long-term global impressions and functioning. Low and high doses of aripiprazole significantly favored placebo for global impressions of severity (CGI-BP overall illness; p <0.05) and functioning (CGAS; p <0.05).^117^ For aripiprazole versus risperidone and quetiapine, no between group differences were seen between groups in terms of global impression of improvement or severity at 4 to 6 months followup;^107^ all groups improved on these outcomes over baseline.

Cognitive functioning. Speed of processing score was lower in patients treated for 4-weeks with ziprasidone than with placebo; however, the level of significance was not reported.^116^

Suicide-related ideations or behaviors, or death by suicide. The suicide attempt rate was pooled for five short-term RCTs^108, 114, 116, 118, 119^ comparing SGAs with placebo (Figure 53); one additional study reported no suicide attempts in either group.^120^ There was no significant difference between the groups (RR, 1.71; 95% CrI, 0.39 to 7.38). Three short-term RCTs^116–118^ reported suicide rates for SGAs versus placebo comparisons. No deaths by suicide occurred in either of the groups across all studies; therefore, a meta-analysis could not be conducted.

Figure 53 SGAs versus placebo for suicide attempts in bipolar disorder

CrI = credible interval; RR = risk ratio; SGA = second-generation antipsychotic

Figure 53 displays a meta-analysis of studies comparing SGAs versus placebo for suicide attempts in bipolar disorder. Our meta-analysis (6 trials, 1079 subjects) showed no difference between groups (RR, 1.71; 95% CrI, 039 to 7.38; I2=0%).

Eight short-term RCTs^108, 109, 116–121^ comparing SGAs with placebo reported rates of suicidal ideation (Figure 54). The pooled estimate showed no significant difference between the groups (RR, 1.12; 95% CrI, 0.58 to 2.26). One study found no difference between ziprasidone and placebo for self-injurious behavior.^116^

Figure 54 SGAs versus placebo for suicide ideation in bipolar disorder

CrI = credible interval; RR = risk ratio; SD = standard deviation; SGA = second-generation antipsychotic

Figure 54 displays a meta-analysis of studies comparing SGAs versus placebo for suicide ideation in bipolar disorder. Our meta-analysis (8 trials, 1578 subjects) showed no difference between groups (RR, 1.12; 95% CrI, 0.58 to 2.26; I2=0%).

Quality of life/wellbeing. The Child Health Questionnaire (CHQ-PF50) was completed by parents in a 3-week study of adolescents taking olanzapine or placebo.^120^ The olanzapine group improved to a greater extent than the placebo group in the Psychosocial summary score (10.7 vs. 6.5 points change, p = 0.03). The Behavior, Family activities, and Mental health subscales also showed significantly greater improvement in mean scores in the olanzapine group than the placebo group (p < 0.05). In both the acute (4-week) and long-term (30-week) phases in a trial comparing low- and high-dose aripiprazole with placebo, there was no difference between groups in quality of life measured by the Pediatric Quality of Life Enjoyment and Satisfaction Questionnaire.^117^

Caregiver burden/strain. One 3-week RCT found no significant difference between quetiapine and placebo in relieving caregiver burden, as assessed by the Caregiver Strain Questionnaire.^119^

### Bipolar Disorder: Within-Study Subgroup Effects

Seven studies examining bipolar disorder conducted an analysis of patient outcomes in different subpopulations (Table 12).^108, 109, 116–120^ All studies were placebo-controlled and evaluated SGAs.

Table 12 Within-study analyses for subgroups of interest in bipolar disorder

First Author, Year Comparison | Type of Analysis | Outcome | Authors’ Conclusions
Findling, 2015^108^ 2.5mg vs. 5mg vs. 10 mg asenapine vs. placebo | Subgroup analysis by comorbidity, cotreatment, onset, sex | YMRS | There was no significant difference in YMRS total score from baseline to day 21 between patients with/without ADHD, with/without concomitant stimulant use, onset of bipolar I disorder ≤11 yr or >11 yr, and gender.
Findling, 2009^117^ Aripiprazole vs. placebo | Subgroup analysis by age, prior treatment, comorbidities | YMRS | Significant findings for YMRS remained for 10–12 and 13–17 yr olds, those with and without prior bipolar treatment, and for those with or without ADHD, ODD
Findling, 2014b^109^ Quetiapine vs. placebo | Subgroup analysis by phase of disorder, bipolar subtypes, age, comorbidities, cotreatment | CDRS-R | No significant mean change in CDRS-R total score (baseline to 8 wk) found for patients with/without rapid cycling, with bipolar I or II disorder, 10–12yr or 13–17yr, patients with comorbid ADHD, patients with comorbid ADHD with/without concomitant psychostimulants
Findling, 2013b^116^ Ziprasidone vs. placebo | Subgroup analysis by comorbidity, key symptoms | YMRS | Ziprasidone was efficacious in subjects who had the key symptoms elation/euphoria or grandiosity. Significant least squares mean difference in comorbid ADHD patients treated with ziprasidone vs. placebo.
Haas, 2009c^118^ Low- vs. high-dose risperidone vs. placebo | Subgroup analysis by age | YMRS | Patients ≤12 and >12 years had significantly more improvement with risperidone than placebo.
Haas, 2009c^118^ Low- vs. high-dose risperidone vs. placebo | Subgroup analysis by sex, race, diagnosis, or hospitalization | YMRS | Risperidone was consistently more effective than placebo regardless or sex, race, diagnosis, or hospitalization at screening.
Pathak, 2013^119^ Low- vs. high dose quetiapine vs. placebo | Subgroup analysis by age, sex, comorbidity, cotreatment | YMRS | There was no significant therapy-by-subgroup interaction on the YMRS for the following subgroups: mania type, rapid cycling, psychosis, ADHD, ODD, or age (10–12 vs.13–17 yr). Concomitant use of psychostimulants did not differentially affect YMRS scores.
Tohen, 2007^120^ Olanzapine versus placebo | Subgroup analysis for comorbidities, bipolar subtypes, use of stimulants | CGI–BP and YMRS | Diagnosis of comorbid ADHD and bipolar diagnostic subtypes did not alter treatment outcomes. Concomitant use of psychostimulants had no effect on YMRS scores.

ADHD = attention deficit hyperactivity disorder; CDRS-R = Children’s Depression rating Scale-Revised; CGI-BP = Clinical Global Impressions of Severity Bipolar; ODD = oppositional defiant disorder; YMRS = Young Mania rating Scale; yr = year

The benefits of SGAs versus placebo for reducing manic^117–119^ and depression^109^ symptoms appear to be similar for children and adolescents (analyses using a cut-off around 12 years). Sex and race had no significant impact on YMRS scores in one placebo-controlled RCT comparing risperidone dosing regimens.^118^ Another study^120^ examined the impact of bipolar subtypes on CGI–BP and YMRS in patients treated with olanzapine. Diagnosis of bipolar diagnostic subtypes did not alter treatment outcomes.^120^ Concomitant use of psychostimulants had no effect on YMRS scores;^108, 109, 119, 120^ comorbid diagnosis of ADHD or a disruptive, impulse-control, or conduct disorder did not effect results either for mania^108, 116, 117, 119, 120^ or depression.^109^

### Autism Spectrum Disorders: Overview

Twenty-three studies examined the effectiveness of FGAs and SGAs in treating patients with autism spectrum disorders (ASD): nineteen RCTs,^122–140^ two controlled before-after studies,^139, 140^ and two retrospective cohort studies.^143, 144^ The majority of the studies reported on intermediate and/or effectiveness outcomes; one RCT only provided data on harms specific to the patients within our age range.^125^ Tables 13 and 14 provide selected information on the characteristics of the individual trials and observational studies, respectively. The studies are grouped according to the drug class comparisons. Studies that include both head-to-head and placebo comparisons are listed under the head-to-head category. Within each comparison, studies are listed alphabetically by the specific drugs compared. Detailed evidence tables are available in Appendix D.

Table 13 Characteristics of trials examining autism spectrum disorders

First Author, Year Study Design, Duration | Intervention (N Enrolled), Dosage (mg/day) Mean±SD | Age, Mean±SD (Range)/Males (%)/White (%) Comorbidities | Diagnosis Breakdown (n) Quality Rating
FGAs vs. SGAs
Malone, 2001^130^ RCT, 6 wk | G1: Haloperidol (6), 1.4±0.7 mg/day G2: Olanzapine (6), 7.9±2.5 mg/day | G1: 7.3±1.9 yr/Male: 67%/White: 67% G2: 8.5±2.4 yr/Male: 67%/White: 50% Comorbidities: MR (mild (1), moderate (5), severe (5)) | autism (11), PDD NOS (1) ROB: High (subjective), Medium (objective)
Miral, 2008^133^ RCT, 12 wk (12 wk extension) | G1: Haloperidol (15), 2.6±1.3 mg/day G2: Risperidone (15), 2.6±0.8 mg/day | G1: 10.9±2.9 yr/Male: 87%/White: NR G2: 10.0±2.7 yr/Male: 73%/White: NR Comorbidities: NR | autism (all) ROB: Medium (subjective), Medium (objective)
FGAs vs. FGAs
Perry, 1989^136^ RCT, 6 mo | G1: Haloperidol (continuous) (34), 1.2 mg/day G2: Haloperidol (discontinuous) (36), 1 mg/day | G1 and G2: 2.3–7.9 yr/Male: 69/White: NR Comorbidities: NR | autism (all) ROB: High (subjective), High (objective)
SGAs vs. SGAs
Ghanizadeh, 2014a^124^ RCT, 8 wk | G1: Aripiprazole (29), 5.5 mg/day G2: Risperidone (30), 1.12mg/day | G1: 9.6±3.3 yr/Male: 86.2%/White: NR G2: 9.5±4.6 yr/Male: 76.6%/White: NR Comorbidities: NR | autism (38), asperger disorder (8), PDD-NOS (9), childhood disruptive behavior disorder (1) ROB: Medium (subjective), Medium (objective)
Hellings, 2006^125^ RCT (cross-over), 6 wk Harms | G1: Risperidone (low) (26), NR G2: Risperidone (high) (26), 2 (1.2–2.9) G3: Placebo (26) | All groups (G1–G3): NR/Male: NR/White: NR Comorbidities: MR (Mild (8), moderate (6), severe (8), profound (4)), PDD-NOS (NR) | NR ROB: High (subjective), High (objective)
Kent, 2013^128^ RCT, 6 wk | G1: Risperidone (low) (30), 0.125–0.175 mg/day G2: Risperidone (high) (31), 1.25–1.75 mg/day G3: Placebo (35) | All groups: Age NR/Male: 88% G1: White: 70% G2: White: 81% G2: White: 57% Comorbidities: NR | autism (all) ROB: Medium (subjective), Medium (objective)
Loebel et al., 2016^127^ RCT, 6 wk | G1: Lurasidone (low)(48), 20 mg/day G2: Lurasidone (high)(51), 60 mg/day G3: Placebo (49) | G1: 10.5±3 yr/Male: 79.2%/White: 79.2% G2: 10.5±3/Male: 84.3%/White: 74.5% G3: 11±3/Male: 81.6%/White: 81.6% Comorbidities: NR | autistic disorder (all) ROB: Medium (subjective), Medium (objective)
Marcus, 2009^131^ RCT, 8 wk | G1: Aripiprazole (low) (53), target: 5 mg/day G2: Aripiprazole (medium) (59), target: 10 mg/day G3: Aripiprazole (high) (54), target: 15 mg/day G4: Placebo (52) | G1: 9.0±2.8 yr/Male: 89%/White: 70% G2: 10.0±3.2 yr/Male: 85%/White: 70% G3: 9.5±3.1 yr/Male: 93%/White: 78% G4: 10.2±3.1 yr/Male: 92%/67% Comorbidities: behavior issues (e.g., tantrums, aggression, self-injury; all) | autism (all) ROB: High (subjective), High (objective)
SGA vs. Placebo
Findling, 2014b^123^ RCT, 16 wk (after 13–26 wk stabilization) | G1: Aripiprazole (41), 2–15 mg/day G2: Placebo (44) | G1: 10.1±2.8 yr/Male: 73.2%/White: 75.6% G2: 10.8±2.8 yr/Male: 86.4%/White: 63.6% Comorbidities: NR | autistic disorder (all) ROB: High (subjective), High (objective)
Hollander, 2006^126^ RCT, 8 wk | G1: Olanzapine (6), 10±2 mg/day G2: Placebo (5) | G1: 9.3±2.9 yr/Male: all/White: 50% G2: 8.9±2.1 yr/Male: 60%/White: 80% Comorbidities: MR (mild (5), severe (2)) | asperger syndrome (1), autism (6), PDD NOS (4) ROB: High (subjective), High (objective)
Luby, 2006^129^ RCT, 6 mo | G1: Risperidone (12), 1.1±0.3 mg/day G2: Placebo (12) | G1: 4.1±0.9 yr/Male: 75%/White: 91% G2: 4.0±1.1 yr/Male: 67%/White: 92% Comorbidities: NR | autistic disorder (NR), PDD NOS (NR) ROB: Medium (subjective), Low (objective)
McCracken, 2002^132^ RCT, 8 wk | G1: Risperidone (49), 1.8±0.7 mg/day G2: Placebo (52) | G1: NR/Male: 80%/White: NR G2: NR/Male: 83%/White: NR Comorbidities: MR (borderline (12), mild or moderate (43), severe (31)), serious behavior issues (all) | autistic disorder (all) ROB: Medium (subjective), Medium (objective)
Nagaraj, 2006^134^ RCT, 6 mo | G1: Risperidone (19), 1 mg/day G2: Placebo (21) | G1: 4.8±1.7 yr/Male: 84%/White: NR G2: 5.3±1.7 yr/Male: 90%/White: NR Comorbidities: Aggression (20), irritability (36), self-injurious behavior (12), seizures (8) | autistic disorder (all) ROB: Low (subjective), Low (objective)
Owen, 2009^135^ RCT, 8 wk | G1: Aripiprazole (47), NR G2: Placebo (51) | G1: 9.7±3.2 yr/Male: 89.4%/White: 68.1% G2: 8.8±2.6yr/Male: 86.3%/White: 80.4% Comorbidities: NR | NR ROB: Medium (subjective), low (objective)
RUPP, 2005^138^ RCT, 8 wk (after 4 mo stabilization) | G1: Risperidone (16), 3.5 (15–45 kg), 4.5 (>45 kg) G2: Placebo (16) | All groups (G1–G2): 9.0±2.5 yr/Male: 86.8%/White: 60.5% Comorbidities: IQ average (2), IQ borderline (5), MR (27) | autistic disorder (all) ROB: Medium (subjective), Medium (objective)
Shea, 2004^139^ RCT, 8 wk | G1: Risperidone (41), 1.2 mg/day G2: Placebo (39) | G1: 7.6 yr/Male: 73%/White: NR G2: 7.3 yr/Male: 82%/White: NR Comorbidities: MR (27) | asperger syndrome (12), autistic disorder (55), childhood disintegrative disorder (1), PDD NOS (11) ROB: Medium (subjective), Medium (objective)
Troost, 2005^140^ RCT, 8 wk (after 24 wk stabilization) | G1: Risperidone (12), 1.9±0.7 mg/day G2: Placebo (12) | G1: 9.4±3.4 yr/Male: 92%/White: 100% G2: 8.7±1.2 yr/Male: 92%/White: 83% Comorbidities: behavior issues (e.g., tantrums, aggression, or self-injury; all), MR (2) | asperger syndrome (2), autistic disorder (6), PDD NOS (16) ROB: Low (subjective), Low (objective)
FGA vs. Placebo
Anderson, 1989^122^ RCT (cross-over), 4 wk | G1: Haloperidol, Placebo, Placebo (14), 0.84±0.57 mg/day G2: Placebo, Haloperidol, Placebo (14), 0.84±0.57 mg/day G2: Placebo, Placebo, Haloperidol (14), 0.84±0.57 mg/day | All groups: 4.49±1.16 yr/Male: 77.8%/White: NR Comorbidities: mild/low level MR (42), of these, profoundly or severely MR (29) | austistic disorder (all) ROB: High (subjective), Medium (objective)
Remington, 2001^137^ RCT (cross-over), 7 wk | G1: Chlomipramine-Placebo-Haloperidol (CPH), PHC, HCP (33), 1–1.5 mg/day | G1: 16.3 (10–36) yr/Male: 83.3%/White: NR Comorbidities: NR | austistic disorder (all) ROB: High (subjective), High (objective)

FGA = first-generation antipsychotic; G = group; KQ = key question; Mg = milligram; mo = month; MR = mental retardation; N = number; NOS = not otherwise specified; NR = not reported; PDD = pervasive developmental disorder; RCT = randomized controlled trial; ROB = risk of bias; SD = standard deviation; SGA = second-generation antipsychotic; wk = week; yr = year

Table 14 Characteristics of observational studies examining autism spectrum disorders

First Author, Year Study Design, Duration | Intervention (N Enrolled), Dosage (mg/day) Mean±SD | Age, Mean±SD (Range)/Males (%)/White (%) Comorbidities | Diagnosis Breakdown (n) Quality Rating
SGAs vs. SGAs
Novaes, 2008^143^ Retrospective cohort, 17 mo | G1: Risperidone or risperidone and FGA (13 and 5), NR G2: Other SGA with or without FGA (8), NR | All patients: 4–21 yr/Male: 89/White: NR Comorbidities: aggression/agitation (all), MR (20) | autistic disorder (all) 8/8 stars
Wink, 2014^144^ Retrospective cohort, 1.5 (aripiprazole) – 2.4 (risperidone) yr | G1: Risperidone (72), 2.23±1.30 mg/day G2: Aripiprazole (70), 11.85±7.23 mg/day | G1: 8.41±3.59 yr/Male: 83.3%/White: 77.8% G2: 9.74±3.46 yr/Male: 80%/White: 75.7% Comorbidities: intellectual disability (64) | autistic disorder (84), PDD-NOS (48), asperger’s disorder (10) 7/8 stars
SGA vs. Placebo/No treatment
NCT00619190^141^ Controlled before-after, 12 wk | G1: Aripiprazole (21), 1–30 mg/day G2: No treatment as per parental desire (9) | G1: 8.3±3.8 yr/Male: 90%/White: NR G2: 11.1±4.5 yr/Male: 89%/White: NR Comorbidities: NR | autism spectrum disorders (30) 4/8 stars
Mankoski, 2013^142^ Retrospective (pooled analysis), see Marcus 2009 & Owen 2009 Subgroup analysis for harms | G1: Aripiprazole (antipsychotic naïve, 176), NR G2: Placebo (naive, 80), NR G3: Aripiprazole (prior antipsychotic exposure, 36), NR G4: Placebo (prior exposure, 21), NR | All groups: mean (9.4–10) yr/Male: NR/White: NR Comorbidities: NR | NR 6/8 stars

FGA = first-generation antipsychotic; G = group; KQ = key question; Mg = milligram; mo = month; MR = mental retardation; N = number; NOS = not otherwise specified; NR = not reported; PDD = pervasive developmental disorder; RCT = randomized controlled trial; ROB = risk of bias; SD = standard deviation; SGA = second-generation antipsychotic; wk = week; yr = year

Overall, the average age of patients was 9.1 years. Patients were predominantly male (average 83%) and White (72%; not reported in 11 studies). All studies included patients with ASD, with varying numbers specific to categories of pervasive developmental disorder, Asperger Syndrome, etcetera. In four studies, all enrolled patients had behavioral issues, such as tantrums, aggression, or self-injury. ^131, 132, 140, 143^ Global developmental delay was present in 24 percent of all patients across the studies.

Two studies provided head-to-head evidence for comparisons of an FGA (haloperidol) with SGAs (olanzapine or risperidone).^130, 133^ One RCT^136^ compared the long-term effectiveness of continuous (daily) versus discontinuous (5 days per week) administration of haloperidol. Two studies compared two SGAs (aripiprazole and risperidone),^124, 144^ one compared risperidone to other SGAs,^143^ and 13 compared an SGA (N = 8 for risperidone) with placebo.^123,125–129, 131, 132, 134, 135, 138–140^, Four RCTs compared different doses of SGAs,^125, 127, 128, 131^ although one of them only for harms outcomes.

Treatment duration varied widely across studies (range, 4 weeks to 2.3 years). For the studies we considered short-term (< 6 month duration), average duration was 8.9 weeks. Four other studies provided 6-month data,^129, 133, 134, 136^ and two provided data for longer than 12 months.^143, 144^ Eight of 18 trials (44 percent) had a high ROB, mainly due to incomplete outcome data and unclear allocation concealment. Two of the four observational studies were of high quality/low ROB, one had moderate and another had poor quality.

### Autism Spectrum Disorders: Intermediate Outcomes

Seventeen studies reported on intermediate outcomes for treating ASD. A summary of the key findings by comparison is provided below. Table 15 contains the findings and SOE ratings for key outcomes assessed as having at least low SOE; the reason for each SOE decision is included in the table footnotes. A detailed analysis follows for the findings, organized by comparison.

Table 15 Strength of evidence for autism spectrum disorders: Key intermediate outcomes having at least low strength of evidence

Comparison | Outcome (N Studies; N Patients) | Findings,^a^ Studies, and Tool With Range of Values, if Applicable | Strength of Evidence; Conclusions
SGAs vs. placebo | Irritability (8, 809) | MD, −6.38; 95% CrI, −8.94 to −3.83 (ABC subscale; range 0–45 )^123, 127, 128, 131, 132, 135, 139, 140^ | Moderate; SGAs probably decrease^b^
SGAs vs. placebo | Lethargy/social withdrawal (7, 743) | MD, −1.67; 95% CrI, −3.05 to −0.28 (ABC subscale; range 0–48)^123, 127, 131, 132, 135, 139, 140^ | Moderate; SGAs probably decrease slightly^b^
SGAs vs. placebo | Stereotypy (5, 634) | MD, −1.73; 95% CrI, −3.16 to −0.05 (ABC subscale; range 0–21) ^127,131, 132, 135, 139^ | Moderate; SGAs probably decrease slightly^b^
SGAs vs. placebo | Inappropriate speech (7, 743) | MD, −1.04; 95% CrI, −1.83 to −0.26 (ABC subscale; range 0–12)^123, 127, 131, 132, 135, 139, 140^ | Moderate; SGAs probably decrease slightly^b^
SGAs vs. placebo | Response rates (7, 716) | RR, 2.22; 95% CrI, 1.29 to 4.17^126, 127, 128, 131, 132, 133, 137^ | Moderate; SGAs probably increase^b^
SGAs vs. placebo | Relapse rates (3, 141) (Maintenance phase only) | RR, 0.30; 95% CrI, 0.07 to 0.84^123, 138, 140^ | Low; SGAs may decrease in maintenance phase^c^
SGAs vs. placebo | Global impressions of improvement on CGI-I^d^ (6, 635) | 4 RCTs: MD, −1.00, 95% CrI, −2.34 to −0.07^126, 127, 131, 135^ 2 RCTs: RR 4.5^128^ and 6.5^132^; both p < 0.01 (proportion scoring as at least “much improved”) | Low; SGAs may increase^e^
SGAs vs. placebo | Global impressions of severity on CGI-S^d^ (4, 522) | 4 RCTs: MD, −0.61; 95% CrI, −1.04 to −0.15 ^127, 128, 131, 135^ | Moderate; SGAs probably decrease slightly^b^
Aripiprazole vs. placebo | Irritability (3, 393) | MD, −5.74; 95% CrI, −9.34 to −2.15 (ABC subscale; range 0–45 )^123, 1231, 135^ | Moderate; Aripiprazole probably decreases^b^
Aripiprazole vs. placebo | Lethargy/social withdrawal (3, 393) | MD, −1.41; 95% CrI, −4.19 to 1.35 (ABC subscale; range 0–48)^123, 131, 135^ | Low; Aripiprazole may make little or no difference^e^
Aripiprazole vs. placebo | Stereotypy (3, 393) | MD, −2.51; 95% CrI, −4.68 to −0.33 (ABC subscale; range 0–21)^123, 131, 135^ | Moderate; Aripiprazole probably decreases slightly^b^
Aripiprazole vs. placebo | Inappropriate speech (3, 393) | MD, −1.49; 95% CrI, −3.02 to 0.06 (ABC subscale; range 0–12)^123, 131, 135^ | Low; Aripiprazole may make little or no difference^e^
Risperidone vs. placebo | Irritability (4, 268) | MD, −8.28; 95% CrI, −12.59 to −3.64 (ABC subscale; range 0–45 )^128, 132, 139, 140^ | Moderate; Risperidone probably decreases^b^
Risperidone vs. placebo | Lethargy/social withdrawal (3, 202) | MD, −2.51; 95% CrI, −5.67 to 1.02 (ABC subscale; range 0–48)^132, 139, 140^ | Low; Risperidone may make little or no difference^e^
Risperidone vs. placebo | Stereotypy (2, 178) (Acute phase only) | 1 RCT: −3.10; 95% CI, −4.93 to −1.27^132^ 1 RCT: −1.90; 95% CI, −3.64 to −0.16^139^ (ABC subscale; range 0–21) | Low; Risperidone may decrease slightly for acute treatment^c^
Risperidone vs. placebo | Inappropriate speech (3, 202) | MD, −1.06; 95% CrI, −2.66 to 0.59 (ABC subscale; range 0–12)^132, 139, 140^ | Low; Risperidone may make little or no difference^e^
Risperidone vs. placebo | Response rate (3, 246) | RR, 2.75; 95% CrI, 0.92 to 9.77^128, 1302 139^ | Low; Risperidone may make little or no difference^e^

ABC = Aberrant Behavior Checklist; CB-YOCS = Children’s Yale-Brown Obsessive Compulsive Scale; CGI-I = Clinical Global Impressions of Improvement; CGI-S = Clinical Global Impressions of Severity; CI = confidence interval; CrI = credible interval (used with Bayesian meta-analysis); MD = mean difference; N = number; RCT: randomized controlled trial; RR = risk ratio; SGA = second-generation antipsychotics

a When the findings are not representative of the total number of studies identified in the outcome column, we included the number of studies for each finding; we did not pool data from 1 or 2 studies so these results are always presented separately. All values except Response are favorable for SGAs when there is a negative MD, or a RR < 1.0 (i.e., relapse); the larger the magnitude of effect, the larger the effect.

b Downgraded for ROB.

c Downgraded for ROB and imprecision because of small sample size, typically < 200 patients in total.

d CGI-S and CGI-I scores range from 0–6.

e Downgraded for ROB and imprecision, because credible interval includes a clinically significant value (e.g., lower boundary value considered clinically meaningful reduction) such that we could not rule out benefit even though effect estimate appears to be of no difference.

#### Key Points

- FGAs versus SGAs (two RCTs^130, 133^): The comparative effectiveness is not known for outcomes of anger, hyperactivity, or global impressions of improvement or severity.
- Aripiprazole versus risperidone (one RCT^124^): For reported outcomes of irritability, inappropriate speech, lethargy, social withdrawal, hyperactivity, and stereotypy, the comparative effects of aripiprazole and risperidone are not known.
- SGAs—Dose comparisons (aripiprazole^131^, lurasidone ^127^ and risperidone^128^): Different doses of aripiprazole, lurasidone, or risperidone have unknown effects on irritability, lethargy/social withdrawal, stereotypic behavior, speech impairment, conduct problems, and global impressions of improvement.
- SGAs versus placebo (ten RCTs [aripiprazole,^123, 131, 134^ lurasidone, ^127^ olanzapine,^126^ and risperidone.^128, 132, 138–140^] and one controlled before-after study^141^): SGAs probably decrease irritability, and decrease slightly lethargy/social withdrawal, stereotypy, inappropriate speech, and compulsions. They probably increase response rates and improve slightly illness severity. They may increase global impressions of improvement. Maintenance treatment with an SGA may decrease relapse rates. When examining studies of aripiprazole and risperidone separately, these SGAs probably decrease irritability, but there may be little or no difference for lethargy/social withdrawal and inappropriate speech. The smaller sample sizes contributing to the SOE for each drug likely affected the ability to obtain a significant finding for most outcomes (e.g., response rates), with the exception of irritability which overall had the larger magnitude of effect. Observations of between-study subgroup effects: (a) findings suggested that the relative effect between SGAs and placebo are reduced to a small extent in patients previously stabilized on the SGA; (b) the dose of SGAs was fairly similar between studies examining the same drug—for risperidone, one of the acute phase RCTs administered a slightly larger dose (1.8 mg/day^132^ vs. 1.2^139^ and 1.25–1.75^128^ mg/day) than the others and this appeared to heighten its effect for several outcomes.

#### Detailed Analysis

##### FGAs Versus SGAs

Two RCTs compared FGAs versus SGAs for intermediate outcomes.^130, 133^

Haloperidol versus olanzapine. A 6-week RCT compared haloperidol with olanzapine in children ages 5 to 17 years.^130^ Using factors on the CPRS sensitive to antipsychotic treatment of autism, patients on olanzapine showed significantly greater improvement for anger and hyperactivity (p = 0.05 and p = 0.01, respectively), but not for the autism factor (p = 0.56) or the speech deviance factors. Global impressions of severity (p = 0.08) and improvement (p = 0.25) did not significantly differ between groups.

Haloperidol versus risperidone. A 12-week RCT assessed the comparative effectiveness of haloperidol and risperidone in children ages 8 to 18 years.^133^ Risperidone led to significantly greater improvement in nonspecific symptoms measured by the Aberrant Behavior Checklist (ABC) total score (p = 0.006). On the Ritvo-Freeman Real Life Rating Score, the risperidone group had improvement (p < 0.01) in all five subscales (sensory-motor, social, affect, sensory, language) while haloperidol failed to offer significant improvement in the sensory (p = 0.21) and language (p = 0.051) subscales.

##### SGAs Versus SGAs

One RCT compared two SGAs^124^ and three RCTs^127, 128, 131^ compared different doses of SGAs for intermediate outcomes.

Aripiprazole versus risperidone. An 8-week RCT compared aripiprazole with risperidone for their safety and efficacy on irritability.^124^ There were no differences between groups for changes in symptoms of irritability (p = 0.06; aripiprazole numerically favorable), inappropriate speech (p = 0.3), lethargy/social withdrawal (p = 0.5), hyperactivity (p = 0.5), or stereotypy (p = 0.6) measured using ABC subscales. There was also no difference between groups for number of patients showing at least “much improvement” in global impressions of improvement (p = 0.3).

Aripiprazole–Low- versus medium- versus high-dose. An 8-week, placebo-controlled RCT evaluated the efficacy of daily fixed-dose regimens of aripiprazole at 5 mg, 10 mg, and 15 mg on irritability associated with autistic disorder.^131^ The high-dose aripiprazole group had significantly greater improvement for lethargy/social withdrawal symptoms (ABC subscale) than the medium-dose group (p = 0.05). No differences were found between any groups for other ABC scores (i.e., irritability, speech impairment) (all p > 0.3), conduct problems (Children’s Yale-Brown Obsessive Compulsive Scale [CY-BOCS]; all p > 0.2), or for global impressions of improvement (all p >0.65) or severity (all p > 0.5).

Lurasidone – Low-versus high-dose. A 6-week, placebo-controlled RCT compared low-dose 20 mg/day and high-dose 60 mg/day lurasidone and found no differences between groups for irritability, global impressions of improvement, hyperactivity, stereotypic behavior, inappropriate speech, lethargy/withdrawal, or for compulsion.^127^

Risperidone–Low- versus medium- versus high-dose. A 6-week, placebo-controlled RCT compared low-dose (0.125–0.175 mg/day) and high-dose (1.25–1.75 mg/day) risperidone.^128^ The high-dose group was superior to placebo for symptoms of irritability (p < 0.001) and compulsions (p = 0.003), response rates (p = 0.004), and global impressions of improvement (p < 0.001), but not for inappropriate speech or social withdrawal (both p > 0.5). The low dose group showed no benefit over placebo for all outcomes.

##### SGAs Versus Placebo

Ten RCTs compared SGAs with placebo for intermediate outcomes: aripiprazole,^123, 131, 135^, lurasidone,^127^olanzapine,^126^ and risperidone.^128, 132, 138–140^ A 12-week controlled before-after study^141^ compared a group taking open-label aripiprazole with another withheld from antipsychotic treatment as per parental desire. A total of 997 patients with an average age of 9.3 years were enrolled in the studies. The average treatment duration was 10 weeks. The majority of patients were males (84.9%) and white (72%). Six of the RCTs examined SGAs in the context of acute treatment in patients either naïve (> 80% in those reporting on previous exposure)^128, 131, 132, 135^ to or not taking antipsychotics; three RCTs^123, 138, 140^ studied the effects of placebo-controlled discontinuation of an SGA after stabilization on the SGA.

###### Meta-Analysis for SGAs Versus Placebo in Autism Spectrum Disorders

Meta-analyses were conducted to compare SGAs with placebo for short-term symptoms of irritability, lethargy/social withdrawal, stereotypy, inappropriate speech, and compulsions. Nonspecific symptoms that were examined using meta-analysis include response rates, relapse rates, and discontinuations due to lack of efficacy; data on global impression of illness severity and improvement were also pooled across studies. Because of clinical heterogeneity, sensitivity analyses were conducted for several outcomes when there was some indication of statistical heterogeneity (I^2^ >20%) and studies examining placebo-controlled maintenance treatment were included (Findling 2014b^123^, RUPP 2005^138^, and Troost 2005^140^). There were three studies comparing multiple doses of an SGA with placebo; we combined the results for the three doses (5, 10, and 15 mg/day) of aripiprazole^131^ and two doses of lurasidone (20 and 60 mg/day),^127^ but for the other study^128^ we did not use data for the low-dose (0.125–0.175 mg/day) risperidone group which was found inferior to the higher dose for all outcomes and was considerably lower than approved by the FDA (1–3 mg/day).

Short-term core symptoms. Data were reported for all subscales of the ABC by seven RCTs^123, 127, 131, 132, 135, 139, 145^; one RCT^128^ only provided sufficient data for the irritability subscale. Each subscale has a different range of possible values (lower scores better) which is important for interpretation: irritability (0–45), lethargy/social withdrawal (0–48), stereotypy (0–21), inappropriate speech (0–12) were used for short-term symptoms.

Results for irritability indicated significantly greater reductions for the SGAs (MD, −6.38; 95% CrI, −8.94 to −3.83; I^2^ = 65%) (Figure 55). Removing two studies of maintenance (Findling 2014b^123^ and Troost 2005^140^) increased the magnitude of the effect estimate slightly although did not reduce the statistical heterogeneity (MD, −6.68; 95% CrI, −9.75 to −3.61; I^2^ = 74%). When pooling the results for each drug, there was a larger effect estimate for risperidone although considerable heterogeneity (risperidone: MD, −8.28; 95% CrI, −12.59 to −3.64; I^2^ = 55%, and aripiprazole: MD, −5.74; 95% CrI, −9.34 to −2.15; I^2^ = 0%). In the controlled before-after study,^141^ the aripiprazole group had higher irritability scores (7.6 points) at study endpoint over baseline, while the no treatment control group has a slight reduction (−0.6 points) (between-group p value = 0.0002).

Figure 55 SGAs versus placebo for irritability using ABC in autism spectrum disorders

ABC = Aberrant Behavior Checklist; CrI = credible interval; SD = standard deviation; SGA = second-generation antipsychotic; MD = mean difference

Figure 55 displays a meta-analysis of studies reporting the mean difference of irritability using ABC in autism spectrum disorders with use of SGAs versus placebo. Our meta-analysis (8 trials, 850 subjects) showed significantly greater reductions in irritability with use of SGAs versus placebo (MD, −6.38; 95% CrI, −8.94 to −3.83; I2=50%). Separate meta-analyses for Risperidone (4 trials, 301 subjects; MD, −8.28; 95% CrI, −12.59 to −3.64; I2=55%) and Aripiprazole (3 trials, 401 subjects; MD, −5.74; 95% CrI, −9.34 to −2.15; I2=0%) showed similar results.

SGAs were also favorable over placebo for lethargy/social withdrawal (MD, −1.67; 95% CrI, −3.05 to −0.28; I^2^ = 0%) (Figure 56). No sensitivity analysis was conducted for the maintenance studies.^123, 140^ Separate meta-analyses for risperidone (MD, −2.51; 95% CrI, −5.67 to 1.02) and aripiprazole (MD, −1.41; 95% CrI, −4.19 to 1.35) showed no difference from placebo for either SGA. The controlled before-after study of aripiprazole versus no treatment^141^ found greater reduction in lethargy/social withdrawal scores for the aripiprazole compared with no treatment group (4.2 points lower; p = 0.01).

Figure 56 SGAs versus placebo for lethargy/social withdrawal using ABC in autism spectrum disorders

ABC = Aberrant Behavior Checklist; CrI = credible interval; MD = mean difference; SD = standard deviation; SGA = second-generation antipsychotic

Figure 56 depicts a meta-analysis of studies reporting the mean difference of lethargy/social withdrawal using ABC in autism spectrum disorders with use of SGAs versus placebo. Our meta-analysis (7 trials, 754 subjects) showed SGAs were favorable over placebo (MD, −1.67; 95% CrI, −3.05 to −0.28; I2=0%). Separate meta-analyses for Risperidone (3 trials, 205 subjects; MD, −2.51; 95% CrI, −5.67 to 1.02; I2=55%) and Aripiprazole (3 trials, 401 subjects; 95% CrI, −1.41; 95% CrI, −4.19 to 1.35; I2=0%) showed no difference between groups.

Results for stereotypy indicated significantly greater reductions for the SGAs (MD, −1.73; 95% CrI, −3.16 to −0.05; I^2^ = 62%) (Figure 57). Sensitivity analysis by removing two studies of maintenance increased the magnitude of the effect estimate slightly but did not reduce the statistical heterogeneity (MD, −2.09; 95% CrI, −3.84 to −0.38; I^2^ = 54%). We pooled the results for aripiprazole and found similar results in favor of this SGA (MD, −2.51; 95% CrI, −4.68 to −0.33). We did not pool the results for risperidone because of the influence on heterogeneity from the maintenance study by Troost and colleagues.^140^

Figure 57 SGAs versus placebo for stereotypy using ABC in autism spectrum disorders

ABC = Aberrant Behavior Checklist; CrI = credible interval; MD = mean difference; SD = standard deviation; SGA = second-generation antipsychotic

Figure 57 displays a meta-analysis of studies reporting the mean difference of stereotypy using ABC in autism spectrum disorders with use of SGAs versus placebo. Our meta-analysis (7 trials, 754 subjects) showed SGAs were significant in reducing stereotypy in comparison with placebo (MD, −1.73; 95% CrI, −3.16 to −0.05; I2=49%). Specific to Aripiprazole (3 trials, 401 subjects) were similar (MD, −2.51; 95% CrI, −4.68 to −0.33; I2=0%).

The symptom of inappropriate speech was reduced significantly (MD, −1.04; 95% CrI, −1.83 to −0.26; I^2^ = 39%) (Figure 58). Separate meta-analyses for aripiprazole and risperidone failed to show significant benefit for the individual SGAs (aripiprazole: MD, −1.49; 95% CrI, −3.02 to 0.06, and risperidone: MD, −1.06; 95% CrI, −2.66 to 0.59); these results are likely due to the imprecision resulting from analyzing few studies.

Figure 58 SGAs versus placebo for inappropriate speech using ABC in autism spectrum disorders

ABC = Aberrant Behavior Checklist; CrI = credible interval; MD = mean difference; SD = standard deviation; SGA = second-generation antipsychotic

Figure 58 shows a meta-analysis of studies reporting the mean difference of inappropriate speech using ABC in autism spectrum disorder with use of SGAs versus placebo. Our meta-analysis (7 trials, 754 subjects) showed SGAs significantly reduced the symptom of inappropriate speech when compared with placebo (MD, −1.04; 95% CrI, −1.83 to −0.26; I2=0%). Results specific to Aripiprazole (3 trials, 401 subjects; MD, −1.49; 95% CrI, −3.02 to 0.06; I2=0%) and Risperidone (3 trials, 205 subjects; MD, −1.05; 95% CrI, −2.66 to 0.59; I2=0%) did not show significant benefit for the individual SGAs.

A meta-analysis of five RCTs^126, 127, 131, 132, 135^ examining compulsions using the CY-BOCS compared SGAs to placebo (Figure 59). The pooled estimate indicated no significant improvement for patients taking SGAs (MD, −1.52; 95% CrI, −3.65 to 0.62). We did not conduct meta-analysis for any individual drug.

Figure 59 SGAs versus placebo for compulsions using CY-BOCS in autism spectrum disorders

CY-BOCS = Children’s Yale-Brown Obsessive Compulsive Scale; CrI = credible interval; MD = mean difference; SD = standard deviation; SGA = second-generation antipsychotic

Figure 59 shows a meta-analysis of studies reporting the mean difference of compulsions using CY-BOCS in autism spectrum disorders with use of SGAs versus placebo. Our meta-analysis (5 trials, 428 subjects) showed no significant improvement in this outcome for patients taking SGAs versus placebo (MD, −1.52; 95% CrI, −3.65 to 0.62; I2=76%).

Short-term nonspecific symptoms. Meta-analyses were conducted to compare SGAs with placebo for response rates, relapse rates, and discontinuations for lack of efficacy (Figures 60–62). Patients taking SGAs showed more than twice the response than those taking placebo (RR, 2.22; 95% CrI, 1.29 to 4.17). The average doses of the two RCTs of aripiprazole were quite similar.^131, 135^ The estimated RR for the three risperidone studies^128, 132, 139^ was 2.75, and it was not significant (95% CrI, 0.92 to 9.77); the statistical heterogeneity may in part relate to the slightly higher dose of risperidone in one of the studies (McCracken 2002)^132^ than the others.^128, 139^

Figure 60 SGAs versus placebo for response rates in autism spectrum disorders

CrI = credible interval; RR = risk ratio; SGA = second-generation antipsychotic

Figure 60 displays a meta-analysis of studies reporting on response rates in autism spectrum disorders with use of SGAs versus placebo. Our meta-analysis (7 trials, 752 subjects) showed twice the response for those taking SGAs compared with those taking placebo (RR, 2.22; 95% CrI, 1.29 to 4.17: I2=60%). Specific to Risperidone (3 trials, 277 subjects) results were similar but not significant (RR, 2.75; 95% CrI, 0.92 to 9.77; I2=70%).

Figure 61 SGAs versus placebo for relapse rates in autism spectrum disorders

CrI = credible interval; RR = risk ratio; SD = standard deviation; SGA = second-generation antipsychotic

Figure 61 displays a meta-analysis of studies reporting on relapse rates in autism spectrum disorders with use of SGAs versus placebo. Our meta-analysis (3 trials, 141 subjects) showed a significant effect favoring maintenance on a SGA compared to placebo (RR, 0.30; 95% CrI, 0.07 to 0.84; I2=43%).

Figure 62 SGAs versus placebo for discontinuation due to lack of efficacy in autism spectrum disorders

CrI = credible interval; RR = risk ratio; SGA = second-generation antipsychotic

Figure 62 displays a meta-analysis of studies reporting on discontinuation due to lack of efficacy in autism spectrum disorders with use of SGAs versus placebo. Our meta-analysis (6 trials, 679 subjects) showed discontinuation due to lack of efficacy was lower for treatment groups using SGAs versus placebo (RR, 0.36; 95% CrI, 0.10 to 0.88; I2=33%). Specific to Aripiprazole (3 trials, 401 subjects) results were similar but not significant (RR, 0.33; 95% CrI, 0.04 to 1.31; I2=54%). The same can be said for results specific to Risperidone (3 trials, 278; RR, 0.21; 95% CrI, 0.03 to 1.52; I2=11%).

Meta-analysis of relapse rates (based on irritability symptoms and overall clinical impressions) for three RCTs^123, 138, 140^ examining placebo-controlled maintenance of SGAs in patients with ASD found a significant effect favoring maintenance on a SGA compared with placebo (RR, 0.30; 95% CrI, 0.07 to 0.84) (Figure 61). Discontinuation due to lack of efficacy was lower for treatment groups across seven RCTs comparing SGAs with placebo (RR, 0.36; 95% CrI, 0.10 to 0.88; I^2^ = 33%) (Figure 62). When pooling data for only those studies examining the acute phase of treatment, the results favored the SGAs even more (RR, 0.22; 95% CrI, 0.06 to 0.81).

Short-term global impressions. Four RCTs provided data for meta-analyses of SGAs versus placebo for global impressions of improvement^126, 127, 131, 135^ (Figure 63) and severity (Figure 64).^127, 128, 131, 135^ Results found no difference for global improvement (MD, −1.00, 95% CrI, −2.34 to 0.07; I^2^ = 72%) but showed significant improvement for global severity (MD, −0.61; 95% CrI, −1.04 to −0.15; I^2^ =0%). There was considerable heterogeneity in the results for global improvement likely resulting from the Hollander^126^ study which was small and enrolled a high proportion of patients with mild or moderate mental retardation. Results were different for studies of risperidone providing data for the proportion of patients scored as at least “much improved” on the CGI-I (RR, 4.5^128^ and 6.5^132^; both p < 0.01). The controlled before-after study of aripiprazole versus no treatment found lower CGI-S scores for (therefore favoring) the no treatment group at study endpoint (0.85 points lower; p = 0.01).^141^

Figure 63 SGAs versus placebo for global impressions of improvement in autism spectrum disorders

CGI-I = Clinical Global Impression of Improvement; CrI = credible interval; MD = mean difference; SD = standard deviation; SGA = second-generation antipsychotic

Figure 63 displays a meta-analysis of studies comparing SGAs versus placebo for global impressions of improvement in autism spectrum disorders. Our meta-analysis (4 trials, 475 subjects) showed no significant improvement with use of SGAs versus placebo (MD, −1.00; 95% CrI, −2.34 to 0.07; I2=67%).

Figure 64 SGAs versus placebo for global impressions of severity in autism spectrum disorders

CGI-S = Clinical Global Impressions of Severity; CrI = credible interval; MD = mean difference; SD = standard deviation; SGA = second-generation antipsychotic

Figure 64 depicts a meta-analysis of studies comparing SGAs versus placebo for global impressions of severity in autism spectrum disorders. Our meta-analysis (4 trials, 560 subjects) showed significant improvement with use of SGAs versus placebo (MD, −0.61; 95% CrI, −1.04 to −0.15; I2=0%).

Lifestyle behaviors. Seven RCTs^126, 128, 131, 132, 135, 139, 141^ provided data for a meta-analysis on increases in appetite for children in comparisons between SGAs and placebo (Figure 65). Because increased appetite may contribute to increased weight which is considered a potential harm for these drugs, the results are considered to significantly favor placebo (RR, 2.37; 95% CrI, 1.38 to 4.10). A 6-month study^129^ (N = 23) of risperidone versus placebo found 55 and 25 percent, respectively, of children stated they had an increase in appetite (p = 0.15).

Figure 65 SGAs versus placebo for increases in appetite in autism spectrum disorders

CrI = credible interval; RR = risk ratio; SGA = second-generation antipsychotic

Figure 65 shows a meta-analysis of studies reporting on increased in appetite for children in autism spectrum disorders with use of SGAs versus placebo. Our meta-analysis (7 trials, 634 subjects) showed results that significantly favored placebo (RR, 2.37; 95% CrI, 1.38 to 4.10; I2=0%).

###### Additional Findings

Individual studies found that risperidone improved symptoms more than placebo for the following measures: the conduct problem, hyperactive, insecure, and overly sensitive subscales of the Nisonger Child Behavior Rating Form (NCBRF) parent version (p < 0.05),^139^ Ritvo-Freeman Real Life Rating Score (p < 0.001),^132^ Vineland Adaptive Behavior Scale–maladaptive subscale (p < 0.001),^132^ and Visual Analog Scale of the most troublesome symptom (p ≤ 0.05).^139^

###### Observations on Between-Study Subgroup Effects

Apart from type of SGA, the primary difference between the studies comparing SGAs with placebo was the treatment history of the patients. We performed sensitivity analyses in cases showing some statistical heterogeneity, to examine the influence on the results. Our findings suggested that the relative effect between SGAs and placebo are reduced to a small extent in patients previously stabilized on the SGA. The response to the SGAs appears greater for patients when they are first prescribed the drug.

The dose of SGAs was fairly similar between studies. For risperidone, one of the acute phase RCTs administered a slightly larger dose (1.8 mg/day^132^ vs. 1.2^139^ and 1.25–1.75^128^ mg/day) than the others which appeared to heighten its effect for several outcomes.

### Autism Spectrum Disorders: Effectiveness Outcomes

Ten studies reported on effectiveness outcomes in ASD. Four RCTs^129, 133, 134, 136^ and two observational studies^143, 144^ provided treatment durations of 6 months or longer. A summary of the findings on key outcomes is provided below. The SOE for all key outcomes was assessed as insufficient due to ROB, unknown consistency (most outcomes), and imprecision. A brief description of the long-term studies is provided, followed by details on findings by outcome category.

#### Key Points

- FGAs versus SGAs (one RCT^133^): Global improvement and language was examined between risperidone and haloperidol, but the effects are unknown due to insufficient SOE.
- FGAs versus FGAs (one RCT^136^): The evidence was insufficient to determine if a difference in effect exists for clinical impressions of improvement and symptom severity between groups taking continuous or discontinuous (5 days per week) haloperidol for 6 months.
- SGAs versus SGAs (two retrospective cohort studies^143, 144^): Studies examined risperidone versus aripiprazole for global improvement scores at end of greater than 1.5 year followup,^144^ and risperidone versus other SGAs^143^ for global improvement, but we had no confidence to make any conclusions on effects.
- SGAs versus placebo (six RCTs^127,129, 131, 132, 134, 140^): Compared with placebo, the effects from risperidone for language or socialization skills, ^129^ 6-month global functioning, ^134^ and cognitive tasks^132^ are not known. The comparative effects of two doses of lurasidone^127^ and three doses of aripiprazole^131^ versus placebo on suicide-related behaviors are not known.

#### Detailed Analysis

##### Description of Long-Term Studies

FGAs versus SGAs. A 12-week RCT with a 12-week extension assessed the comparative effectiveness of haloperidol and risperidone.^133^

FGA versus FGAs. A 6-month RCT randomized children to continuous or discontinuous drug administration of haloperidol.^136^ The discontinuous drug schedule consisted of 5 days on haloperidol with 2 days on placebo. The prescribed dose of haloperidol was similar between the groups (1.2 mg/day in the continuous group, and 1.0 mg/day in the discontinuous group).

SGAs versus SGAs. A retrospective cohort study compared risperidone with aripiprazole after mean treatment durations 2.4 and 1.5 years, respectively.^144^ Another retrospective study compared effects on agitation and aggression of risperidone compared with other SGAs (quetiapine, aripiprazole, and olanzapine); both groups in this analysis had patients taking concomitant FGAs.^143^

SGAs versus placebo. Two 6-month RCTs compared risperidone with placebo in young children with ASD.^129, 134^ The children in one of these RCTs^129^ were also receiving intensive behavioral therapy (Applied Behavioral Analysis).

##### Results on Effectiveness Outcomes From Short- and Long-Term Studies

Long-term core symptoms. Risperidone led to significantly greater improvement than haloperidol for the language subscale of the Ritvo-Freeman Real Life Rating Score (p = 0.04).^133^ No difference was found in one RCT^129^ for language or socialization skills when comparing risperidone with placebo.

Long-term nonspecific symptoms. Two RCTs comparing risperidone with placebo assessed children for overall autism symptoms using the Childhood Autism Rating Scale.^129, 134^ Luby et al.^129^ found no difference between groups (p = 0.14), while Nagaraj et al.^134^ found that risperidone was favored significantly with 6 points greater reduction (p < 0.0001) and 12 of 19 versus 0 of 20 showing 20 percent or greater improvement in total Childhood Autism Rating Scale scores. The difference between studies may relate to the intensive behavioral therapy provided to all children in the study by Luby et al.^129^

Long-term global impressions and functioning. The proportion of patients improving by at least two points of the CGI-I or CGI-S did not differ between groups taking continuous or discontinuous haloperidol for 6 months (p = 0.32 and 0.48).^136^ Risperidone was favored over haloperidol for CGI-I scores at 24 weeks (p = 0.02).^133^ In studies comparing different SGAs, groups taking risperidone and aripiprazole did not differ in global improvement scores at end of 1.5 years or greater followup (p = 0.32),^144^ and there was no difference between groups taking risperidone and other SGAs in the proportion of patients attaining one or two points improvement on the CGI-I (p = 0.75).^143^ Global functioning was improved significantly more for children taking risperidone than placebo in one 6-month RCT;^134^ 17 of 19 versus 2 of 20 children improved by at least 20 percent on the C-GAS (p = 0.035).

Cognitive functioning. Two short-term RCTs^132, 140^ comparing risperidone and placebo reported patients’ performance on various cognitive tasks. Risperidone was superior to placebo on a visuospatial (“dot”) task; no differences were found between groups for cancellation tasks, word recognition, and hand-eye coordination.^132^ Similarly, reaction time did not differ between groups.^140^

Suicide-related ideations or behaviors, or death by suicide. In an 8-week RCT^131^ comparing three doses of aripiprazole with placebo, three patients in the placebo group (N = 52) displayed suicide-related behaviors compared to no patients in the aripiprazole groups (N =166). In a 6-week RCT comparing two doses of lurasidone with placebo, one patient in the 60 mg group (N=51) had suicidal ideation leading to study discontinuation compared with no patients in the 20 mg group (N=49) and placebo group (N=49).

### Autism Spectrum Disorders: Within-Study Subgroup Effects

Five studies of autism spectrum disorders conducted an analysis of outcomes in different subpopulations (Table 16).^123, 132, 136, 138, 143^

Table 16 Within-study analysis for subgroup effects

First Author, Year Comparison | Type of Analysis | Outcome | Authors’ Conclusions
McCracken, 2002^132^ Risperidone vs. placebo | Moderator analyses for sex, age, ethnicity, income, IQ | ABC-I | None of the variables were a significant moderator of response to risperidone.
| Mediator analyses for dose | ABC-I | Dose had a strong and significant point bi-serial correlation with treatment; children taking risperidone were likely to receive lower doses than children randomized to placebo.
Findling, 2014b^123^ Aripiprazole vs. placebo | Subgroup analysis by race, age | Relapse | Aripiprazole treatment resulted in significantly lower relapse rate among white patients; non-significant results for non-white patients. No significant age interaction observed between the 2 groups (aripiprazole vs. placebo).
RUPP, 2005^138^ Risperidone vs. placebo | Regression analysis for age, IQ, baseline ABC irritability | Relapse | There was no significant difference in age, IQ and baseline ABC irritability scores between relapsing and non-relapsing patients.
Perry, 1989^136^ Continuous haloperidol vs. discontinuous haloperidol | Subgroup analysis by age, developmental quotient, baseline rating scores | Severe deterioration (CGI–I difference) | Patients with high baseline CPRS Conduct Problem Factor scores and patients with significant improvement before the antipsychotic withdrawal regimen showed significant deterioration than patients without these variables. All other variables did not predict deterioration.

ABC-I = Aberrant Behavior Checklist Irritability subscale; CGI-I = Clinical Global Impressions of Improvement; CPRS = Conner’s Parent Rating Scale; IQ = intelligence quotient

Four studies found no significant effect of age on response^141^ or relapse^123, 132, 136^ after treatment with a variety of FGAs and SGAs, including aripiprazole, risperidone, and haloperidol. Race/ethnicity did not moderate response for irritability in one study of risperidone;^132^ another study found aripiprazole to lower relapse rates in white but not non-white patients.^123^

### ADHD and Disruptive, Impulse-Control, or Conduct Disorders: Overview

Thirteen studies examined the effectiveness of antipsychotics for treating patients with ADHD and/or DICD.^146–158^ Tables 17 and 18 provide selected information on the characteristics of the individual studies. Studies are organized within their respective comparison (head-to-head then placebo-controlled), and then alphabetically by drug name and then by author. There was only one head-to-head drug comparison. Both observational studies were pooled analyses of two of the included RCTs;^146, 149^ one provided data for subgroup effects for patients using stimulants, and the other provided data for cognitive function. Detailed evidence tables are available in Appendix D.

Table 17 Characteristics of trials examining ADHD and disruptive, impulse-control, or conduct disorders

First Author, Year, Study Design, Duration | Intervention (N Enrolled), Dosage (mg/day) Mean±SD | Age, Mean±SD (Range)/Males (%)/White (%) Comorbidities | Diagnosis Breakdown (n), Quality Rating
FGAs vs. FGAs
Stocks, 2012^148^ RCT, 8–11 wk | G1: Molindone (20), <30 kg: 5 mg/day; ≥ 30 kg: 10 mg/day G2: Molindone (19), <30 kg: 10 mg/day; ≥ 30 kg: 20 mg/day G3: Molindone (19), <30 kg: 15 mg/day; ≥ 30 kg: 30 mg/day G4: Molindone (20), <30 kg: 20 mg/day; ≥ 30 kg: 40 mg/day | G1: 8.5±1.88 yr/Male: 95%/White: 55% G2: 9.4±1.98 yr/Male: 84.2%/White: 57.9% G3: 8.8±2.12 yr/Male: 68.4%/White: 42.1% G4: 8.8±2.00 yr/Male: 95%/White: 65% Comorbidities: Asthma (13), CD (8), Eczema (6), Enuresis (12), Environmental allergies (4), Insomnia (5), ODD (26), Seasonal allergies (5) | ADHD (78) ROB: High (subjective), High (objective)
SGAs vs. Placebo
Aman, 2014^147^ RCT (parallel), 6 wk | G1: Risperidone + stimulant + parent training (84), 1.7±0.75 mg/day G2: Placebo + stimulant + parent training (84), 1.9±0.72 mg/day | G1: 9.03±2.05 yr/Male: 77.4%/White: 57.1% G2: 8.75±1.98 yr/Male: 76.2%/White: 48.8% Comorbidities: CD (44), ODD (124) | ADHD (168) ROB: Medium (subjective), Medium (objective)
Aman, 2009^152^ RCT (cross-over), 2 wk (after 1 yr treatment duration) | G1: Risperidone (16),^*^ 1.7±1.3 mg/day G2: Placebo (16)^*^ | All groups: 8.6±2.6 yr/Male : 88%/White: 81% Comorbidities: MR (borderline (10), mild (4), moderate (1)) | ADHD with CD (2), ADHD with ODD (6), ADHD only (1), ASD (3), CD (1), ODD (3) ROB: Medium (subjective), Medium (objective)
Aman, 2002^151^ RCT, 6 wk | G1: Risperidone (55), 1.2±0.6 mg/day G2: Placebo (63) | G1: 8.7±2.1 yr/Male: 85%/White: 51% G2: 8.1±2.3 yr/Male: 79%/White: 62% Comorbidities: ADHD (70), MR (all; borderline (60), mild (38), moderate (20)) | CD (47), DBD (8), ODD (63) ROB: High (subjective), High (objective)
Armenteros, 2007^153^ RCT, 4 wk | G1: Risperidone (12), 1.1±0.6 mg/day G2: Placebo (13) | G1: 7.3±3.7 yr/Male: 83%/White: 50% G2: 8.8±3.1 yr/Male: 92%/White: 46% Comorbidities: GAD (1), ODD (13), separation anxiety disorder (3) | ADHD with aggression (all) ROB: Medium (subjective), Medium (objective)
Buitelaar, 2001^154^ RCT, 6 wk | G1: Risperidone (19), 2.9 mg/day G2: Placebo (19) | G1: 14.0±1.5 yr/Male: 90%/White: NR G2: 13.7±2 yr/Male: 84%/White: NR Comorbidities: ADHD (26), anxiety disorder (3), MR (14) | CD (30), DBD NOS (2), ODD (6), aggression (all) ROB: Medium (subjective), Medium (objective)
Findling, 2000^156^ RCT, 10 wk | G1: Risperidone (10), 0.028±0.004 mg/kg/day G2: Placebo (10) | G1: 10.7±3.4 yr/Male: NR/White: NR G2: 8.2±1.9 yr/Male: NR/White: NR Comorbidities: ADHD (0) | CD with aggression (all) ROB: High (subjective), High (objective)
Reyes, 2006^157^ RCT, 6 mo | G1: Risperidone (172), 0.81±0.34 mg/day (<50 kg), 1.22±0.36 mg/day (≥50 kg) G2: Placebo (163) | G1: 10.9±2.9 yr/Male: 82%/White: NR G2: 10.8±2.9 yr/Male: 91%/White: NR Comorbidities: ADHD (227) | CD (123), DBD NOS (8), ODD (204) ROB: High (subjective), High (objective)
Snyder, 2002^158^ RCT, 6 wk | G1: Risperidone (53), 1±0.73 mg/day G2: Placebo (57) | G1: 8.6±0.3 yr/Male: 77%/White: 79% G2: 8.8±0.3 yr/Male: 74%/White: 74% Comorbidities: ADHD (84), MR (all; borderline (53), mild (42), moderate (15)) | CD (41), ODD (69) ROB: High (subjective), High (objective)
Connor, 2008^155^ RCT, 6 wk | G1: Quetiapine (9), 294±78 mg/day G2: Placebo (10) | G1: 13.1±1.2 yr/Male: 78%/White: 78% G2: 15±1.4 yr/Male: 70%/White: 70% Comorbidities: ADHD (15), depression (4), dysthymia (5), GAD (3), OCD (3), ODD (18), panic disorder (1), PTSD (3), SA (6), separation anxiety (3), social phobia (3) | CD with moderate to severe aggression (all) ROB: High (subjective), High (objective)
FGAs vs Placebo
Aman, 1991^150^ RCT (cross-over), 3 wk | G1: Thioridazine (30)^*^, 1.75 mg/kg/day G2: Placebo (30)^*^ | All groups: 10.0 (4.1–16.5) yr/Male: 83%/White: 70% Comorbidities: Significantly subnormal IQ(<76) (27), PDD (1) | ADHD (24), ADD (4), ADD Residual type (1), CD (3) ROB: Medium (subjective), Medium (objective)

ADHD = attention deficit hyperactivity disorder; ASD = autism spectrum disorder; CD = conduct disorder; DBD = disruptive behavior disorder; G = group; GAD = general anxiety disorder; KQ = key question; mg = milligrams; mo = month; MR = mental retardation (as used by studies); N = number; NOS = not otherwise specified; NR = not reported; OCD = obsessive-compulsive disorder; ODD = oppositional defiant disorder; PTSD = post-traumatic stress disorder; RCT = randomized controlled trial; ROB = risk of bias; SA = substance abuse; SD = standard deviation; wk = week; yr =- year

* All patients experienced each of the treatment arms in this cross-over study

Table 18 Characteristics of observational studies examining ADHD and disruptive, impulse-control, or conduct disorders

First Author, Year, Study Design, Duration | Intervention (N Enrolled), Dosage (mg/day) Mean±SD | Age, Mean±SD (Range)/Males (%)/White (%) Comorbidities | Diagnosis Breakdown (n) Quality Rating
SGAs vs. Placebo
Aman, 2004^149^ Observational (pooled analysis, see Aman 2002 and Snyder 2002), 6 wk Subgroup data only | G1: Risperidone (43), 1.11 mg/day G2: Risperidone + stimulant (35), 1.07 mg/day G3: Placebo (39) G4: Placebo + stimulant (38) | G1: 8.6±2.1 yr/Male: 81.4%/White: 55.8% G2: 9.0±1.7 yr/Male: 85.7%/White: 65.7% G3: 8.3±2.2 yr/Male: 74.4%/White: 56.4% G4: 8.9±2.1 yr/Male: 92.1%/White: 73.7% Comorbidities: ADHD (all) | CD/ODD/DBD-NOS (breakdown not provided) 7/8 stars
Pandina, 2007^146^ Observational (pooled analysis, see Aman 2002 and Snyder 2002), 6 wk | G1: Risperidone (108), 1.3±0.7 mg/day G2: Placebo (88) | G1: 8.6 yr/Male: 81%/White: 64% G2: 8.4 yr/Male: 77%/White: 68% Comorbidities: ADHD (155) | CD (88), ODD (59), Axis 1 (71), BD NOS (10) 6/8 stars

ADHD = attention deficit hyperactivity disorder; CD = conduct disorder; DBD = disruptive behavior disorder; G = group; mg = milligrams; mo = month; N = number; NOS = not otherwise specified; ODD = oppositional defiant disorder; SD = standard deviation; wk = week

Patients had an average age of 9.9 years and were predominantly male (83%); apart from two RCTs enrolling adolescents,^154, 155^ the age of participants was typically below 12 years. Among 11 studies that reported race/ethnicity, the majority (62%) of patients self-reported as being white. Across the eleven RCTs, children had a primary diagnosis of ADHD in four^147, 148, 150, 153^ and of DICD in 7;^151, 152, 154–158^ all trials except one^156^ had a large proportion of children with comorbid diagnoses of either DICD or ADHD, respectively. Patients were required to have aggression to be included in five of the trials.^147, 153–156^ Common comorbidities apart from ADHD and DICD were global developmental delay and anxiety disorders.

Most RCTs examined acute phase treatment in patients either naïve to or not taking antipsychotics upon enrollment; one RCT enrolled children maintained on risperidone for 1 year and examined placebo-controlled discontinuation of the antipsychotic.^152^ All children were taking stimulants in three RCTs,^147, 148, 153^ variable numbers were taking stimulants in five RCTs,^1451, 152, 154, 157, 158^ and stimulants were prohibited in three RCTs.^150, 155, 156^

The duration of treatment ranged from 2 weeks^152^ to 6 months^157^. For the 10 RCTs lasting less than 6 months, the duration of treatment was on average 6.8 weeks. Six of 11 RCTs had a high ROB; in all cases the high risk was from incomplete outcome data, that is, ≥ 30 percent withdrawals or significant imbalance in reasons for withdrawals between groups.

### ADHD and Disruptive, Impulse-Control, or Conduct Disorders: Intermediate Outcomes

Ten studies reported on intermediate outcomes for using FGAs and SGAs in the treatment of ADHD and DICD. A summary of the findings for our key outcomes is provided below, followed by the results on the SOE for those outcomes assessed as having at least low SOE (Table 19). The section ends with a detailed analysis of the findings by comparison.

Table 19 Strength of evidence findings for ADHD and disruptive, impulse-control, or conduct disorders: Key intermediate outcomes having at least low strength of evidence

Comparison | Outcome (N Studies; N Patients) | Findings,^a^ Studies | Strength of Evidence; Conclusions
SGAs vs. placebo | Conduct problems (6, 462) | SMD, −0.77; 95% CrI, −1.34 to −0.17^147, 151, 152, 155, 154, 156^ | Moderate; SGAs probably decrease ^b^
SGAs vs. placebo | Aggression (7, 495) | SMD, −0.43; 95% CrI, −0.67 to −0.14^145, 149, 151–154, 156^ | Moderate; SGAs probably decrease^b^
SGAs vs. placebo | Global impressions of improvement using CGI-I^c^ (7, 482) | 5 RCTs: RR, 2.13; 95% CrI, 0.87 to 6.46 (proportion at least “improved”)^147, 151, 153, 1, 158^ 1 RCT: MD, −0.50; 95% CI, −1.99 to 0.99^153^ 1 RCT: MD, −1.80; 95% CI, −2.89 to −0.71^156^ | Low; SGAs may make little or no difference^d^
SGAs vs. placebo | Global impressions of severity using CGI-S (3, 75) (Studies of primary treatment in DICD) | 3 RCTs: MD, −1.98; 95% CrI, −3.18 to −0.93^153–156^ | Low; SGAs may decrease in DICD^e^
Risperidone vs. placebo | Conduct problems (5,443) | SMD, −0.84; 95% CrI, −1.54 to −0.18^145, 149, 150, 154, 156^ | Moderate; Risperidone probably decreases^b^
Risperidone vs. placebo | Aggression (6, 476) | SMD, −0.44; 95% CrI, −0.72 to −0.13^147, 151, 153, 154, 156, 158^ | Moderate; Risperidone probably decreases^b^
Risperidone vs. placebo | Hyperactivity (6, 468) | SMD, −0.39; 95% CrI, −0.76 to −0.07^147, 151, 152, 156, 158^ 1 RCT: No difference p > 0.05^151^ | Moderate; Risperidone probably decreases in children not on, or responding to, stimulants^b^
Risperidone vs. placebo | Global impressions of improvement using CGI-I (6, 463) | 4 RCTs: RR, 1.85; 95% CrI, 0.64 to 5.58 (proportion at least “improved”)^147, 151, 153, 158^ 1 RCT: MD, −0.50; 95% CI, −1.99 to 0.99^153^ 1 RCT: MD, −1.80; 95% CI, −2.89 to −0.71^156^ | Low; Risperidone may make little or no difference^d^
Risperidone vs. placebo | Global impressions of severity using CGI-S (2, 56) (Studies of primary treatment in DICD) | 1 RCT: MD, −1.80; 95% CI, −2.54 to −1.06^154^ 1 RCT: MD, −2.50; 95% CI, −4.11 to −0.89^156^ | Low; Risperidone may improve in DICD^e^
Risperidone vs. placebo | Global impressions of severity using CGI-S (2, 193) (Studies of stimulant augmentation in ADHD) | 1 RCT: MD, 0.0; 95% CI, −1.65 to 1.65^153^ 1 RCT: RR, 1.2; 95% CI, 0.95 to 1.5 (proportion rated as “normal/borderline/mildly ill”)^147^ | Low; Risperidone may make little or no difference in ADHD treatment augmented with risperidone^d^
Risperidone vs. placebo | Response rate (2, 193) (Patients with primarily ADHD and aggression) | 1 RCT:^147^ RR, 1.12; 95% CI, 0.94 to 1.34 1 RCT:^153^ RR, 1.28; 95% CI, 0.93 to 1.77 | Low; Risperidone may make little or no difference^d^

CGI-S = Clinical Global Impressions of Severity; CI = confidence interval; CrI = credible interval (used with Bayesian meta-analysis); DICD = disruptive, impulse-control, and conduct disorders; MD = mean difference; N = number; RCT: randomized controlled trial; RR = risk ratio; SGA = second-generation antipsychotics

a When the findings are not representative of the total number of studies identified in the outcome column, we included the number of studies for each finding; we did not pool data from 1 or 2 studies so these results are always presented separately. All effect estimates reported as MD or SMD values favor SGAs when they are negative (larger magnitude greater effect); a RR >1.0 favor SGAs. SMDs provide results in standard deviation units, and are used when the results from different measurement tools are combined in meta-analysis; as a general rule, an absolute magnitude of 0.2 represents a small effect size, 0.5 a moderate one, and 0.8 a large one.

b Downgraded for ROB.

c CGI-S and CGI-I scores range from 0–6.

d Downgraded for ROB and imprecision, because credible interval includes a clinically significant value (e.g., RR ≤0.75 or ≥1.25) such that we could not rule out benefit even though effect estimate appears to be of no difference.

e Downgraded for ROB and impression due to small sample size

#### Key Points

- FGAs—Dose comparison (one RCT^148^): The SOE was insufficient from an RCT examining four doses of molindone for conduct problems, inattention, hyperactivity/impulsivity, or global impression of severity.
- SGAs versus placebo (eight RCTs [risperidone^147, 151–154, 156, 158^ and quetiapine^155^]): SGAs as a class, and risperidone alone, likely reduce conduct problems and aggression in children with ADHD and/or DICD. Results for clinical impressions of improvement showed little or no difference, although results were imprecise and indicated that many patients may possibly improve. Risperidone likely reduces hyperactivity, although this conclusion is specific to studies where not all patients were taking stimulants, or to the situation of nonresponse to stimulants. Clinical severity may be reduced by SGAs and risperidone individually; the results for risperidone do not apply to the study of risperidone augmentation of stimulants and parent training. Risperidone may make little or no difference over placebo for global impressions of improvement. For patients with a primary diagnosis of ADHD and exhibiting aggression, risperidone may make little or no difference for response. Observations on between-study subgroup effects: (a) risperidone may preferentially reduce illness severity, and increase global improvement ratings, for DICD compared with ADHD particularly when used for ADHD as adjunctive treatment; (b) our meta-analysis favored SGAs for hyperactivity, although the data came from studies that did not enroll children responding to stimulants as did another study^153^ that found no benefit for risperidone on hyperactivity; (c) sensitivity analyses by removing the small study enrolling children with a long-term history of response to risperidone did not affect the results;^152^ and (d) we did not find any evidence to suggest a differential treatment effect between studies having different inclusion criteria related to intellectual functioning.
- FGAs versus placebo (one RCT^150^): The effects of thioridazine versus placebo for conduct problems, hyperactivity, anxiety, and global functioning are not known.

#### Detailed Analysis

##### FGAs Versus FGAs

Molindone—Four-dose comparison. A 9- to 12-week RCT compared four doses of molindone in children with ADHD and persistent conduct problems.^148^ No differences (p = 0.58) were found between doses for conduct problems measured using the NCBRF conduct problem subscale; although not significant, changes from baseline for the high-dose (40 mg/day; 20 mg/day if < 30 kg body weight) group were approximately 6 points greater than for the other doses between 10 and 30 mg/day (14.3 points vs. 7.0 to 8.7 points). Similar results were found using the Swanson, Nolan, and Pelham rating scale (SNAP-IV) for inattention (8.15 vs. 4.4 to 6.8 points) and hyperactivity/impulsivity (8.5 vs. 5.42 to 5.8 points), and for global impressions of severity on the CGI-S (1.7 vs. 1.0 to 1.26 points).

##### SGAs Versus Placebo

Quetiapine versus placebo. A 6-week, placebo-controlled RCT assessed the effectiveness of quetiapine for treating adolescents with conduct disorder and aggression.^155^

Risperidone versus placebo. Seven RCTs compared risperidone and placebo for intermediate outcomes.^147, 151–154, 156, 158^ Treatment durations were between 2 and 10 weeks (average 6 weeks). Overall, 606 children and adolescents ranging from age 4 to 17 years participated in the trials. The average age of participants was between 8 and 10 years, with the exception of one study with an average age around 14 years.^154^ Mean daily risperidone doses ranged from 0.8 to 2.9 mg/day, with the higher doses administered to older participants. Most studies examined acute treatment; one enrolled patients responding to risperidone and is considered a maintenance study.^152^

###### Meta-Analysis for SGAs Versus Placebo in ADHD and/or DICD

Meta-analyses were conducted to compare SGAs with placebo for the short-term core symptoms of conduct problems, aggression, and hyperactivity. Data was pooled for the short-term nonspecific outcomes of aberrant behaviors using the ABC total and hyperactivity/noncompliance subscale scores, and for the rate of discontinuation due to lack of efficacy. Short-term global impressions of improvement and severity were also captured.

Where applicable, we conducted meta-analysis for quetiapine and risperidone separately as well as together. Sensitivity analysis was considered for the risperidone studies, in cases where statistical heterogeneity existed (> 20%) and clinical heterogeneity was related to either the diagnostic composition or treatment history of the patients.

Short-term core symptoms. Six RCTs provided data for the outcome of conduct problems (Figure 66).^147, 151, 152, 155, 156, 158^ We used data from three different subscales to generate an SMD for this outcome: the NCBRF conduct problem subscale,^151, 152, 158^ the NCBRF Typical IQ version conduct and oppositional behaviors scores (D-total subscale),^147^ and the CPRS conduct problem subscale.^155, 156^ For SGAs overall, there was a significant beneficial effect for treatment over placebo (SMD, −0.77; 95% CrI, −1.34 to −0.17). Assessing risperidone by itself resulted in a slightly larger magnitude of effect (SMD, −0.84; 95% CrI, −1.54 to −0.18). There was moderate statistical heterogeneity and removing the maintenance study (Aman 2009)^152^ did not change the results or degree of heterogeneity.

Figure 66 SGAs versus placebo for conduct problems in ADHD and/or disruptive, impulse-control, or conduct disorders

ADHD = attention deficit hyperactivity disorder; CrI = credible interval; SD = standard deviation; SGA = second-generation antipsychotic; SMD = standardized mean difference

Figure 66 displays a meta-analysis of studies reporting the standard mean difference of conduct problems in ADHD and/or disruptive, impulse-control, or conduct disorders with use of SGAs versus placebo. Our meta-analysis (6 trials, 467 subjects) showed a significant beneficial effect of treatment with SGAs versus placebo (SMD, −0.77; 95% CrI, −1.34 to −0.17; I2=68%). Specific to Risperidone (5 trials, 448 subjects) results were similar (SMD, −0.84; 95% CrI, −1.54 to −0.18; I2=71%).

For meta-analysis of aggression, we used data from total scores on the Overt Aggression Scale,^154^ Rating of Aggression Against People and/or Property scale,^156^ and Children’s Aggression Scale-Parent version,^153^ and aggression scores from the ADHD Symptom Checklist version 4 (ADHD-SC4),^147^ and the Behavior Problems Inventory (Figure 67).^151, 158^ The pooled results favored SGAs with no statistical heterogeneity (SMD, −0.43; 95% CrI, −0.67 to −0.14). For risperidone alone, the effect estimate was very similar with an SMD of −0.44 (95% CrI, −0.72 to −0.13).

Figure 67 SGAs versus placebo for aggression in ADHD and/or disruptive, impulse-control, or conduct disorders

ADHD = attention deficit hyperactivity disorder; CrI = credible interval; SD = standard deviation; SGA = second-generation antipsychotic; SMD = standardized mean difference

Figure 67 shows a meta-analysis of studies reporting the standard mean difference of aggression in ADHD and/or disruptive, impulse-control, or conduct disorders with use of SGAs versus placebo. Our meta-analysis (6 trials, 479 subjects) favored SGAs versus placebo (SMD, −0.43; 95% CrI, −0.67 to −0.14; I2=0%). Specific to Risperidone (5 trials, 460 subjects) results were similar (SMD, −0.44; 95% CrI, −0.72 to −0.13; I2=0%).

Data from five RCTs ^147, 151, 152, 156, 158^ that compared risperidone to placebo were pooled to provide an estimate of the effect for the core symptom of hyperactivity (Figure 68). An SMD was generated using data from hyperactivity subscores of the CPRS,^156^ NCBRF Problem Behaviors,^151, 152, 158^ and ADHD-SC4^147^ scales. Only the Aman 2002 study^151^ found a significant reduction in hyperactivity. The pooled result across all studies found that risperidone significantly reduced hyperactivity when compared with placebo (SMD, −0.39; 95% CrI, −0.76 to −0.07; I^2^ = 0%). An additional study assessing risperidone in children with ADHD and aggression (Armenteros)^153^ found no difference (data not provided) between risperidone and placebo for hyperactivity using the CPRS. All of the patients in this study were also taking stimulants which may have confounded the results compared with the other trials; the Aman 2014 study^147^ administered placebo-controlled risperidone as adjunct treatment, although patients having good response to the “basic” stimulant and parent training were not eligible.

Figure 68 SGAs versus placebo for hyperactivity in ADHD and/or disruptive, impulse-control, or conduct disorders

ADHD = attention deficit hyperactivity disorder; CrI = credible interval; SD = standard deviation; SGA = second-generation antipsychotic; SMD = standardized mean difference

Figure 68 shows a forest plot of studies reporting the standard mean difference of hyperactivity in ADHD and/or disruptive, impulse-control, or conduct disorders with use of SGAs versus placebo. Our meta-analysis (5 trials, 448 subjects) showed Risperidone significantly reduced hyperactivity when compared with placebo (SMD, −0.39; 95% CrI, −0.65 to −0.07; I2=0%).

Short-term nonspecific symptoms. Four RCTs^151, 152, 154, 158^ provided data for meta-analyses for aberrant behaviors (Figure 69) and for a combination of hyperactivity and noncompliance symptoms (Figure 70); both were assessed on the ABC using total (range 0–147) and hyperactivity/noncompliance (range 0–48) subscales, respectively. Over the short-term, risperidone significantly reduced aberrant behaviors compared with placebo (MD, −20.28; 95% CrI, −31.24, −8.61; I^2^ = 67%). Sensitivity analysis, with removal of the data from the maintenance study by Aman et al.,^152^ increased the effect estimate slightly but did not reduce the heterogeneity (MD, −21.31; 95% CrI, −34.26 to −7.98; I^2^ = 77%). The effect estimate for hyperactivity/noncompliance was also favorable towards risperidone (MD, −8.34; 95% CrI, −11.45 to −5.18; I^2^ =0%) and did not have heterogeneity.

Figure 69 SGAs versus placebo for aberrant behaviors using ABC total score in ADHD and/or disruptive, impulse-control, or conduct disorders

ABC = Aberrant Behavior Checklist; ADHD = attention deficit hyperactivity disorder; CrI = credible interval; MD = mean difference; SD; standard deviation; SGA = second-generation antipsychotic

Figure 69 displays a meta-analysis reporting the mean difference of aberrant behaviours using ABC total score in ADHD and/or disruptive, impulse-control, or conduct disorders with use of SGAs versus placebo. Our meta-analysis (4 trials, 298 subjects) showed Risperidone significantly reduced aberrant behaviors compared with placebo (MD, −20.28; 95% CrI, −31.24 to −8.61; I2=67%).

Figure 70 SGAs versus placebo for hyperactivity/noncompliance using ABC subscale in ADHD and/or disruptive, impulse-control, or conduct disorders

ABC = Aberrant Behavior Checklist; ADHD = attention deficit hyperactivity disorder; CrI = credible interval; MD = mean difference; SD; standard deviation; SGA = second-generation antipsychotic

Figure 70 displays a meta-analysis of studies reporting the mean difference of hyperactivity/noncompliance using ABC subscale in ADHD and/or disruptive, impulse-control, or conduct disorders. Our meta-analysis (4 trials, 298 subjects) showed results favoring Risperidone versus placebo (−8.34; 95% CrI, −11.45 to −5.18; I2=0%).

Meta-analysis of data from seven RCTs^147, 151, 152, 154–156, 158^ found SGAs superior to placebo (RR, 0.30; 95% CrI, 0.11 to 0.83) for rates of discontinuation due to lack of efficacy (Figure 71). None of the patients in the 2-week (Aman 2009) trial^152^ discontinued for lack of efficacy so the data from this study was not included in the pooled estimate. The magnitude of the pooled RR for risperidone was similar although it failed to reach statistical significance (RR, 0.34; 95% CrI, 0.11 to 1.04).

Figure 71 SGAs versus placebo for rates of discontinuation due to lack of efficacy in ADHD and/or disruptive, impulse-control, or conduct disorders

ADHD = attention deficit hyperactivity disorder; CrI = credible interval; RR = risk ratio; SGA = second-generation antipsychotic

Figure 71 depicts a meta-analysis of studies reporting comparisons of SGAs versus placebo for rates of continuation due to lack of efficacy in ADHD and/or disruptive, impulse-control, or conduct disorders. Our meta-analysis (7 trials, 505 subjects) found SGAs were superior to placebo for rates of discontinuation due to lack of efficacy (RR, 0.30; 95% CrI, 0.11 to 0.83; I2=15%). Specific to Risperidone (6 trials, 486 subjects) the result was similar but not statistically significant (RR, 0.34; 95% CrI, 0.11 to 1.03; I2=22%).

Short-term global impressions. Meta-analysis of data from five RCTs^147, 151, 153, 155, 158^ that compared SGAs with placebo found no difference for the proportion of patients scored as at least “improved” on the CGI-I (RR, 2.13; 95% CrI, 0.87 to 6.46; I^2^ = 97%) (Figure 72). The high degree of heterogeneity may relate to the differences in primary diagnosis, which was ADHD for the two studies (Armenteros 2007 and Aman 2014)^147, 153^ showing nonsignificant effects and conduct disorders for the other three.^151, 155, 158^ Specific to risperidone, the result was similar (RR, 1.85; 95% CrI, 0.64 to 5.58; I^2^ = 97%). Two RCTs reported results for CGI-I using mean scores; one found a significant benefit for risperidone in children with conduct disorders and no concomitant ADHD (1.8-point reduction; p = 0.001),^156^ while the other one found no difference for children having ADHD with aggression (p = 0.51).^153^

Figure 72 SGAs versus placebo for global impression of improvement in ADHD and/or disruptive, impulse-control, or conduct disorders

ADHD = attention deficit hyperactivity disorder; CrI = credible interval; RR = risk ratio; SGA = second-generation antipsychotic

Figure 72 shows a forest plot of studies reporting SGAs versus placebo for global impressions of improvement in ADHD and/or disruptive, impulse control, or conduct disorders. Our meta-analysis (5 trials, 440 subjects) found no difference between SGAs versus placebo for the proportion of patients scored as at least “improved on the CGI-I (RR, 2.13; 95% CrI, 0.87 to 6.46; I2=97%). Specific to Risperidone (4 trials, 421 subjects) results were similar (RR, 1.85; 95% CrI, 0.64 to 5.58; I2=97%).

Four RCTs^153–156^ reported data for global impressions of severity using mean scores from the CGI-S (Figure 73). Meta-analysis of the data estimated the pooled effect as significant in favor of SGAs (MD, −1.69; 95% CrI, −3.05 to −0.18; I^2^ = 45%); removing the study of Armenteros et al.^153^ which focused on risperidone augmentation in ADHD rather than primary treatment of conduct disorders reduced the heterogeneity and increased the precision (MD, −1.99; 95% CrI, −3.18 to −0.93; I^2^ = 0%). We did not pool the studies of risperidone due to heterogeneity. One additional trial^147^ reported the proportion of patients rated at study endpoint as “normal/borderline/mildly ill” using the CGI-S; there was no difference between patients receiving stimulants and parent training and those having the same augmented by risperidone (59 versus 72 percent; p = 0.10). These findings of no difference for stimulant augmentation agree with those of Armenteros et al.^153^

Figure 73 SGAs versus placebo for global impressions of severity in ADHD and/or disruptive, impulse-control, or conduct disorders

ADHD = attention deficit hyperactivity disorder; CrI = credible interval; DICD = disruptive, impulse-control, or conduct disorders; MD = mean difference; SD; standard deviation; SGA = second-generation antipsychotic

Figure 73 displays the results of a meta-analysis comparing SGAs versus placebo for global impressions of severity in ADHD and/or disruptive, impulse-control, or conduct disorders (DICD). Our meta-analysis (4 trials, 102 subjects) showed SGAs were significantly favorable versus placebo for this outcome (MD, −1.69; 95% CrI, −3.05 to −0.18; I2=45%). A specific meta-analysis for DICDs (3 trials, 77 subjects) showed results with increased precision (MD, −1.98; 95% Crl, −3.18 to −0.93; I2=0%).

Medication adherence. Meta-analysis from three RCTs^147, 154, 155^ providing data on medication adherence found no difference between SGAs and placebo (RR, 1.02; 95% CrI, 0.77 to 1.32) (Figure 74). The results of the two studies of risperidone were not pooled although both found no difference between groups. One study^154^ reported treatment adherence using plasma samples. The mean plasma concentration of risperidone in the treatment group was 18±24 ng/mL; no risperidone was detected in patients in the placebo group.

Figure 74 SGAs versus placebo for medication adherence in ADHD and/or disruptive, impulse-control, or conduct disorders

ADHD = attention deficit hyperactivity disorder; CrI = credible interval; RR = risk ratio; SGA = second-generation antipsychotic

Figure 74 displays the results of a meta-analysis comparing SGAs versus placebo for medication adherence in ADHD and/or disruptive, impulse-control, or conduct disorders. Our meta-analysis (3 trials, 225 subjects) found no difference in medication adherence with use of SGAs versus placebo (RR, 1.02; 95% CrI, 0.77 to 1.32; I2=0%).

Lifestyle behaviors. Increased appetite was reported by six RCTs^147, 151, 153, 155, 156, 158^ and meta-analysis found no difference between SGAs and placebo (RR, 2.07; 95% CrI, 0.85 to 5.47) (Figure 75). The results for risperidone were similar (RR, 2.42; 95% CrI, 0.95 to 7.44). A 6-month RCT^157^ of risperidone versus placebo had few reports of increased appetite by either the risperidone (4 of 172) or placebo groups (0 of 163) (p = 0.15). Although the relative risk was not statistically significant, in every study of risperidone there were more patients in the treatment than placebo group experiencing increased appetite.

Figure 75 SGAs versus placebo for increased appetite in ADHD and/or disruptive, impulse-control, or conduct disorders

ADHD = attention deficit hyperactivity disorder; CrI = credible interval; RR = risk ratio; SGA = second-generation antipsychotic

Figure 75 shows the results of a meta-analysis of SGAs versus placebo for increased appetite in ADHD and/or disruptive, impulse-control, or conduct disorders. Our meta-analysis (6 trials, 460 subjects) found no difference in appetite between SGAs and placebo (RR, 2.07; 95% CrI, 0.85 to 5.47; I2=0%). Specific to Risperidone (5 trials, 441 subjects) results were similar (RR, 2.53; 95% CrI, 0.95 to 7.44; I2=0%).

###### Additional Findings

Response rates. Two RCTs comparing risperidone and placebo reported treatment response rate in patients with ADHD and aggression. One study^153^ defined response by ≥ 30 percent reduction in aggression, and found no significant difference between the groups (p = 0.13). The other trial’s^147^ response criteria were ≥ 25 percent reduction in NCBRF Typical IQ disruptive behavior score and at least “much improved” on the CGI-I; this study also found no difference between groups (p = 0.22).

Mood symptoms. Two RCTs assessed mood symptoms. Anxiety as measured using the CPRS did not differ between risperidone and placebo group at study endpoint in one study (p = 0.52).^156^ From parent ratings on the Child and Adolescent Symptom Inventory-4R (CASI-4R), risperidone augmentation of stimulants and parent training did not reduce depression symptoms (p = 0.98) or anxiety (p = 0.26) compared with placebo-augmentation.^147^ When teachers completed the CASI-4R in this study, there was a significant reduction in anxiety (p = 0.013) but not depression symptoms (p = 0.18).

Short-term school performance and attendance. Short-term classroom functioning (tests/quizzes, homework, class participation) was rated by teachers as improving with risperidone augmentation of stimulant and parent training, although the results did not reach statistical significance (p = 0.07).^147^ In a 6-week RCT^155^ comparing quetiapine with placebo, no significant differences (p = 0.42) between groups were found for school refusal when captured by an adverse event questionnaire.

###### Observations on Between-Study Subgroup Effects

Clinical and methodological heterogeneity existed between the trials. Although the primary diagnosis differed between studies—in two it was ADHD^147, 153^ and the rest it was DICD^151, 152, 154–156, 158^, most studies enrolled a large proportion of children with DICD or ADHD comorbidities, respectively. Examining the findings for each outcome, there was the suggestion for global impressions of severity that risperidone may preferentially reduce illness severity for conduct disorders compared with ADHD. The metagraphs for other outcomes do not provide any clear support for this observation. The findings of our meta-analysis favored risperidone over placebo for hyperactivity, although the data came from studies that did not enroll children responding to stimulants as with another study^153^ that found no benefit for risperidone on hyperactivity.

In one small trial,^152^ the children all had a long-term history of response to risperidone; removing this study using sensitivity analyses did not affect the results.

Inclusion criterion related to intellectual functioning differed between studies. Three trials^151, 152, 158^ comparing risperidone with placebo limited inclusion to children with subaverage intelligence quotients (IQ 36–84); the children enrolled in other studies of this comparison had higher functioning on average.^147, 153–156^ We did not find any clear evidence of a differential treatment effect between these two groups of studies.

##### FGAs Versus Placebo

A cross-over RCT^150^ assigned children with subaverage intelligence to 3 weeks of methylphenidate, thioridazine, and placebo in random order. Children were assessed using teacher and parent rating scales for multiple symptoms including conduct problems, hyperactivity, anxiety, as well as for global functioning. Teachers’ ratings showed significant improvement for thioridazine compared with placebo for conduct problems (p < 0.01) and hyperactivity (p < 0.001), but no other outcome. Parent ratings failed to find any difference for any outcome between these groups.

### ADHD and Disruptive, Impulse-Control, or Conduct Disorders: Effectiveness Outcomes

Eight studies comparing SGAs with placebo reported on effectiveness outcomes. Key findings are highlighted below, followed by a detailed analysis by comparison and outcome category.

#### Key Points

- SGAs versus placebo (four RCTs^147, 152, 155, 157^ and one observational study^146^): Long-term effectiveness of risperidone compared with placebo is not known for the following outcomes: conduct problems, hyperactivity, relapse, symptom recurrence, time-to-symptom recurrence, and global impressions of severity and functioning.^157^ Growth and maturation,^157^ cognitive tasks,^152,157^ attention,^146^ and quality of life (risperidone and quetiapine)^147,155^ were also examined. The SOE for all outcomes was determined to be insufficient, because of ROB, unknown consistency (for several outcomes) and imprecision due to small samples.
- FGAs versus placebo (one RCT^150^): Cognitive effects of thioridazine versus placebo are unknown due to insufficient SOE.

#### Detailed Analysis

##### SGAs Versus Placebo

Five studies reported on effectiveness outcomes for SGAs versus placebo; the one observational study^146^ was a pooled analysis of data from two RCTs.^151, 158^ One long-term RCT^157^ was conducted in children with DICD (67% with comorbid ADHD) assigned to 6-month maintenance or withdrawal of risperidone treatment after response to 12 weeks of treatment.

###### Results on Effectiveness Outcomes From Short- and Long-Term Studies

Long-term core symptoms. Using the NCBRF, conduct problems (3.3 points; p < 0.001) and hyperactivity (1.6 points; p = 0.007) were reduced significantly more by risperidone than placebo during 6-months maintenance.^157^

Long-term nonspecific symptoms. The 6-month RCT^157^ found risperidone to be significantly superior to placebo for relapse, symptom recurrence, and time-to-symptom recurrence (p ≤ 0.002).

Long-term global impressions. Global impressions of severity (CGI-S) was reduced to a greater extent with maintenance treatment on risperidone (0.6 points; p < 0.001).^157^ Global functioning (C-GAS) was reduced significantly less (3.5 vs. 10.2 points; p <0.001) for maintenance treatment on risperidone versus placebo.^157^

Growth and maturation. One RCT^157^ compared changes in Tanner stages from baseline for patients treated with risperidone or placebo for 6-month maintenance treatment. No group differences in the distribution of stages were observed.

Cognitive and emotional development. Three RCTs and one observational study compared SGAs and placebo for performance on cognitive tasks or adverse effects related to cognition. Risperidone resulted in faster response time, fewer seat movements on a short-term memory task, and fewer contacts (less tremor) on a graduated holes task in one short-term, cross-over trial in children having prolonged response to risperidone (p ≤ 0.05).^152^ A pooled analysis^146^ of patient data from the 6-week trials of Aman^151^ and Snyder^158^ examined results for attention (Continuous Performance Task) and short- and long-term auditory verbal memory (Verbal Learning Test for Children). There was no significant decline in attention for either the risperidone or placebo group; the only treatment group difference was for total commission errors which favored risperidone (p = 0.027). There were no treatment group effects for short- or long-term memory. The longer-term study on maintenance treatment by Reyes et al.^157^ found no difference between groups for verbal learning and attention (Continuous Performance Tasks). The RCT^155^ comparing quetiapine with placebo found significantly fewer adolescent reports of decreased mental alertness for the quetiapine group (p = 0.01).

Quality of life. Risperidone augmentation of stimulants and parent training was shown effective in one short-term study for improving social competence using the NCBRF positive social subscale (p = 0.0049).^147^ In a 6-week RCT^155^ comparing quetiapine with placebo, scores on the Quality of Life Enjoyment and Satisfaction Questionnaire improved significantly in the quetiapine group (by 8 points) compared with the placebo group who worsened by 4 points (p = 0.005). Social withdrawal was assessed in the same RCT;^155^ no difference was found between treatment arms (p = 0.81).

##### FGAs Versus Placebo

One cross-over RCT^150^ with children receiving 3 weeks of methylphenidate, thioridazine, and placebo in random order evaluated cognition using various tests. No differences were found between thioridazine and placebo for tests on IQ performance with reinforcement, breadth of attention, matching-to-sample, short-term memory, attention span (using Continuous Performance Task), seat activity, or for the graduated holes task.

### ADHD and Disruptive, Impulse-Control, or Conduct Disorders: Within-Study Subgroup Effects

Five studies of ADHD and disruptive behavior disorders conducted an analysis of outcomes in different subpopulations (Table 20).^149, 154, 156–158^ All five compared risperidone with placebo.

Table 20 Within-study analyses for subgroups of interest in ADHD and disruptive, impulse-control, or conduct disorders

First Author, Year Comparison | Type of Analysis | Outcome | Authors’ Conclusions
Aman, 2004^149^ Risperidone vs placebo | Subgroup analysis by cotreatment (stimulant vs no stimulant) Additionally, all subjects in this group selected because they have comorbid ADHD | Conduct problems and hyperactivity (NCBRF subscales) | Reduction in conduct problems: 47.2 % (with stimulants) vs. 44.2% (without stimulants), vs placebo 17.6%; patients on stimulants and placebo showed less improvement than those one placebo only. Reduction in hyperactivity improved for risperidone regardless of stimulant use (p < 0.011); addition of risperdione to stimulant significantly improved reduction in hyperactivity (p = 0.0013). No indication that the effects of risperidone varied with stimulant use.
Buitelaar, 2001^154^ Risperidone vs. placebo | Subgroup analysis by IQ and use of prior medication | CGI–S, ABC (school) | No significant difference in rating scale change scores between IQ strata (60–69, 70–79, 80–90) or previous use of medication.
Findling, 2000^156^ Risperidone vs. placebo | Regression analysis by age, race, and baseline RAAPP and CGI–S scores | Completion of study | Age, race, baseline RAAPP score, and baseline CGI–S score was not significantly different between completers and noncompleters.
Findling, 2000^156^ Risperidone vs. placebo | Regression analysis by age, race, and baseline RAAPP and CGI–S scores | RAAPP, CPRS | When an adjustment for age was made, no alteration in rating scales scores were observed
Reyes, 2006^157^ Risperidone vs. placebo | Subgroup analysis by somnolence | CPT | There were no significant difference in the change in any CPT values based on present or absence of somnolence.
Snyder, 2002^158^ Risperidone vs. placebo | Regression analysis by comorbidity, cotreatment, treatment history, condition, gender | NCBRF conduct problem | The efficacy of risperidone was not affected by level of developmental delay, presence of somnolence, ADHD, use of psychostimulants or type of disorder (CD, ODD, DBD–NOS). Conduct problems scores were lower in patients previously treated with risperidone than patients who were risperidone naïve. For the CD subgroup, the NCBRF Conduct Problem subscale showed a significant drug effect (p < 0.002) from week 1 to week 6 and at end point. For the “other disorders” subgroup, the NCBRF Conduct Problem subscale showed a significant effect for risperidone (p < .01).

ABC = Aberrant Behavior Checklist; ADHD = attention deficit hyperactivity disorder; CD = conduct disorder; CGI–S = Clinical Global Impressions–Severity; CPRS = Connor’s Parent Rating Scale; CPT = Continuous Performance Task; DBD = disruptive behavior disorder; IQ = intelligence quotient; NCBRF = Nisonger Child Behavior Rating Form; NOS = not otherwise specified; ODD = oppositional defiant disorder; RAAPP = Rating of Aggression Against People and/or Property

Two studies found no effect of age for effects of risperidone on aggression,^156^ CPRS,^156^ rate of study completion,^156^ and risk of symptom recurrence.^157^ In one study, race was not significantly different in patients who completed the study than those who did not.^156^ Snyder et al.^158^ found no impact of comorbidities (including global developmental delay, ADHD, and secondary diagnosis of disruptive behavior disorders) or cotreatment with psychostimulants on NCBRF conduct problem subscale. Pooled analysis^149^ of the 6-week Snyder^158^ and Aman^151^ trials found no indication that the effects of risperidone on conduct problems or hyperactivity varied with stimulant use. Two studies examined the effect of previous treatment on ABC,^154^ CGI–S,^154^ and NCBRF conduct problem subscale.^158^ Risperidone-naïve patients had lower NCBRF conduct problem scores in one study,^158^ whereas prior treatment had no impact on symptom severity (ABC, CGI–S) in another study.^154^

### Obsessive-Compulsive Disorder: Overview

One 12-week RCT^159^ examined augmentation with risperidone or aripiprazole in patients with obsessive-compulsive disorder (OCD) who failed to respond to at least 12 weeks of treatment with selective serotonin reuptake inhibitors (SSRIs). Patients were mainly male (90%) and had early-onset (average age of onset 8.6 years) OCD. Almost half (49.3%) also received cognitive-behavioral therapy during the study. All had comorbid tic disorders. Details of the study are included in Table 21 and Appendix D. Although differences between groups in comorbidities overall did not reach statistical significance, more patients in the risperidone group had anxiety and phobia disorders, while more patients receiving aripiprazole had comorbid ADHD.

Table 21 Characteristics of studies examining obsessive-compulsive disorder

First Author, Year Study Design, Duration | Intervention (N Enrolled), Dosage (mg/day) Mean±SD | Age, Mean±SD (Range)/Males (%)/White (%) Comorbidities | Diagnosis Breakdown (n) Quality Rating
SGAs vs. SGAs
Masi, 2013^159^ NRCT, ≥12 wk | G1: Risperidone (35), 1.7±0.8 (0.5–3) mg/day G2: Aripiprazole (34), 8.9±3.1 (2.5–12.5) mg/day | G1: 13.3±2.2 yr/Males: 94.3%/White: NR G2: 13.9±2.5 yr/Males: 85.3%/White: NR | OCD with comorbid tic disorders (69) ROB: High (subjective), Medium (objective)

Mg = milligram; N = number; NR = not reported; NRCT = nonrandomized controlled trial; OCD = obsessive-compulsive disorder; ROB: risk of bias; SD = standard deviation; SGA = second-generation antipsychotic; wk = week

### Obsessive-Compulsive Disorder: Intermediate Outcomes

Below we highlight the key points and provide details for the one study’s findings. The SOE for intermediate and effectiveness outcomes in OCD was deemed insufficient.

#### Key Points

- SGAs versus SGAs (one RCT^159^): We are very uncertain of the comparative effects of SSRI augmentation with risperidone and aripiprazole over 12 weeks of treatment for nonspecific symptoms (i.e., response rate) and global impressions of severity and functioning. Results for core symptoms of obsessions and compulsions were not reported by the authors.

#### Detailed Analysis

One RCT^159^ of SGA-augmentation of SSRIs reported on short-term response rates, and on global impressions of improvement, severity, and functioning in terms of OCD symptomatology. Both risperidone and aripiprazole improved all measures over the 12 weeks of treatment. Severity of symptoms (CGI-S) and functioning (C-GAS) improved on average by 2.4 and 13.5 points, respectively (p < 0.0001 for all patients). Response rates were 51.4 and 61.8 percent for risperidone and aripiprazole, respectively. There were no significant differences between risperidone and aripiprazole for severity (p = 0.07), functioning (p = .51), or response rates (p = 0.53). Response to tic symptomatology was similar with 68 percent in both groups responding. Although this study examined patients using the Yale-Brown Obsessive-Compulsive Scale symptom checklist after diagnosis, the authors did not use this data for assessment of treatment effectiveness. No effectiveness outcomes were reported for this study.

### Depression: Overview

One observational study^160^ examined a subgroup of patients aged ≤ 25 years in a pooled analysis of data from two RCTs of placebo-controlled adjuvant aripiprazole (2–20 mg/day) for patients with major depressive disorder who failed to respond to 8 weeks of antidepressant treatment. No details were provided on patient characteristics for the subsample, therefore a table describing study characteristics is not presented.

### Depression: Effectiveness Outcomes

Below we highlight the key points and provide details for the findings from the one study.

#### Key Points

- For SGAs in treatment-resistant depression, we are very uncertain of the effects for intermediate (not reported) and effectiveness outcomes related to suicide; SOE was insufficient because of ROB, unknown consistency, and imprecision (n = 35). No other outcomes were reported.

#### Detailed Analysis

##### SGAs Versus Placebo

One observational study^160^ examined suicide-related adverse events and suicide ideation from placebo-controlled adjuvant aripiprazole in a pooled analysis of two RCTs of adults; separate findings were reported for patients ages ≤ 25 years. Suicide ideation was evaluated using item 10 (suicidality) of the Montgomery-Åsberg Depression Rating Scale (MADRS) and item 18 (suicidality) on the Inventory of Depressive Symptomatology (IDS). No suicides were reported for the entire study population in patients ages 18 to 65. Only 35 patients were aged ≤ 25 years. Three patients experienced worsening on item 10 of the MADRS; one on placebo and one on aripiprazole experienced a 2-point increase on the 7-point scale, and one on placebo experienced a 1-point increase. By comparison, 7 patients on placebo and 7 patients taking aripiprazole experienced 1- or 2-point decreases (improvements) on this item. On the 4-point IDS, one patient (aripiprazole) experienced worsening by 1 point, while three patients in each group experienced a 1- or 2-point decrease (improvement) on this item. No statistical comparisons were made due to the small sample size. Findings for depressive symptomatology were not reported.

### Eating Disorders: Overview

Two RCTs^161, 162^ and one retrospective cohort study^163^ examined SGAs versus placebo for adjunctive treatment in eating disorders. All three studies enrolled females (average ages 14–18) with anorexia nervosa or eating disorders not-otherwise specified (allowing for persistence of menstruation), who were also receiving multidisciplinary, tailored care within eating disorder programs. Details of the studies are reported in Tables 22 and 23, and in Appendix D. The trials were assessed as having medium risk of bias, and the observational study was of good quality.

Table 22 Study characteristics of trials examining eating disorders

First Author, Year, Study Design, Duration | Intervention (N Enrolled), Dosage (mg/day) Mean±SD | Age, Mean±SD (Range)/Males (%)/White (%) Comorbidities | Diagnosis Breakdown (n) Quality Rating
SGAs vs. Placebo
Hagman, 2011^161^ RCT, 11 wk | G1: Risperidone (18), 2.5±1.2mg/day G2: Placebo (22) | G1: 16.2±2.5 yr/Male: 0/White: NR G2: 18.1±2.0 yr/Male: 0/White: NR Comorbidities: depression (NR), obsessive-compulsive disorder (NR), anxiety disorder (NR), bulimia nervosa (NR) | Anorexia nervosa (40) ROB: Medium (subjective), Medium (objective)
Kafantaris, 2011^162^ RCT, 10 wk | G1: Olanzapine (10), target 10 mg/day G2: Placebo (10) | G1: 16.2±2.5 yr/Male: 0/White: Overall (80) G2: 15.8±2.3 yr/Male: 0/White: see G1 Comorbidities: NR | Anorexia nervosa- restricting type ROB: Medium (subjective), Medium (objective)

wk = week; mg = milligram; N = number; NR = not reported; RCT = randomized controlled trial; ROB = risk of bias; SD = standard deviation

Table 23 Characteristics of observational studies examining eating disorders

First Author, Year, Study Design, Duration | Intervention (N enrolled), Dosage (mg/day) mean±SD | Age, mean±SD (range)/Males (%)/White (%) Comorbidities | Diagnosis Breakdown (n) Quality Rating
SGAs vs. Placebo
Norris, 2011^163^ Retrospective cohort | G1: Olanzapine (43), 5.0 (3.75–7.5) [median (IQR)] G2: No antipsychotic treatment (43) Comparisons between groups for weight, n =11/group | G1: 14.4±1.9 yr/Male: 0/White: NR G2: 14.8±1.6 yr/Male: 0/White: NR Comorbidities: Anxiety (42), depression (41), obsessive compulsive disorder (4) | Anorexia nervosa- restricting type (58), anorexia nervosa binge-purge subtype (4), eting disorder NOS (24) ROB: 7/8 stars

IQR = interquartile range; mg = milligram; N = number; NOS = not otherwise specified; NR = not reported; RCT = randomized controlled trial; ROB = risk of bias; SD = standard deviation; wk = week.

### Eating Disorders: Intermediate Outcomes

All studies examining eating disorders compared SGAs with placebo.^161–163^ A summary of the key findings is presented below, followed by a detailed analysis.

#### Key Points

- SGAs versus placebo (olanzapine^162, 163^ and risperidone^161^): We had very little confidence in the effects for all key outcomes (i.e., weight) of relevance; failure to provide data by group (for determining consistency and precision) and the small sample sizes (imprecision) were the main reasons. The studies did not report any effectiveness outcomes.
- Findings from the observational study were substantially confounded by a greater illness severity and overall resource use by the olanzapine group. Speculated changes in resting energy expenditure were not realized.

#### Detailed Analysis

##### SGAs Versus Placebo

Olanzapine versus placebo. A 10-week RCT^162^ examined olanzapine versus placebo for core symptoms of body weight gain and eating disorder symptoms, and for general psychiatric symptoms including depression. Eating disorder symptoms were measured using the Eating Disorder Examination and the Yale-Brown-Cornell Eating Disorder Scale. No difference was found between groups for changes in percent mean body weight (p = 0.88), eating disordered behaviors and attitudes, depression, or general psychiatric symptoms (BPRS). The study only reported data by group for percentage mean body weight. There were also no differences between groups for numbers reporting increased appetite, or for changes in resting energy expenditure.

A retrospective cohort study^163^ attempted to match a group of patients receiving olanzapine with a group not receiving antipsychotics. The authors found that patients treated with olanzapine had significantly greater illness severity (e.g., more comorbidities, more inpatient days, longer treatment course), which greatly confounded their ability to compare these patients with a group not receiving treatment. To minimize confounding, a subgroup of inpatients was analyzed with those in the olanzapine group having received treatment for at least 2 weeks after assessment. Compared to the no treatment group, the olanzapine group had significantly greater weight gain and BMI at discharge, although when examined by rate of weight gain (kg/week) there was no significant differences (p = 0.068). More patients treated with olanzapine were admitted to an intensive treatment program and were treated for longer periods of time than those in the no treatment group.

Risperidone versus placebo. An 11-week RCT^161^compared risperidone with placebo for outcomes of weight (time to reach 90 percent of ideal body weight), eating disorder symptomatology (drive for thinness, body dissatisfaction, body image distortion), anxiety symptoms, and resting energy expenditure. The authors defined five possible endpoints for the study, and timepoints for analyses were 7 and 11 weeks. Risperidone was favored significantly over placebo at 7 weeks (p = 0.002) but not 11 weeks (p = 0.13) on the Drive for Thinness scale on the Eating Disorder Inventory 2. No other significant findings were found for eating disorder symptomatology. Changes over time for anxiety symptoms were not significantly different (p = 0.44); the groups did not differ in changes in percentage of ideal body weight or body mass index (p values not provided). Resting energy expenditure was no different between groups either (p = 0.34).

### Tic Disorders: Overview

Twelve studies (9 RCTs^164–172^ and 3 NRCTs^173–175^) assessed antipsychotics for treating children with tic disorders. Three studies only reported on harm data.^164, 173, 174^ Table 24 provides selected information on the characteristics of the individual studies. The studies are grouped according to the drug class comparisons. Studies that included both head-to-head and placebo comparisons are listed under the head-to-head category. Within each comparison, studies are listed alphabetically by the specific drugs compared. Detailed study characteristic tables are available in Appendix D.

Table 24 Characteristics of trials examining tic disorders

First Author, Year, Study Design, Duration | Intervention (N Enrolled), Dosage (mg/day) Mean±SD | Age, Mean±SD (Range)/Males (%)/White (%) Comorbidities (n) | Diagnosis Breakdown (n) Quality Rating
FGAs vs. SGAs
Yoo, 2011^175^ NRCT, 8 wk | G1: Haloperidol (17), 1.9±1.1 (0.75–4.5) mg/day G2: Aripiprazole (31), 10.6±5.2 (2.5–20) mg/day | G1: 8.6±2.9 (6–16) yr/Male: 64.7%/White: NR G2: 11.2±3.5 (6–18) yr/Male: 71%/White: NR Comorbidities: ADHD (15), ODD (2), OCD (3) | Tourette syndrome (26), chronic motor and vocal tic disorder (11), transient tic disorder (11) ROB: High (subjective), High (objective)
Gulizano, 2011^173^ NRCT, 24 mo Harms | G1: Pimozide (25), 4.4±1.5 mg/day G2: Aripiprazole (25), 5.3±2.4 mg/day | G1: 9.1±2.9 yr/Male: 88%/White: NR G2: 13.1±2.3 yr/Male: 84%/White: NR Comorbidities: ADHD (28), OCD (24) | Tourette syndrome (50) ROB: NA (subjective), Medium (objective)
Rizzo, 2012^174^ NRCT, 24 mo Harms | G1: Pimozide (25), 1–4 mg/day G2: Aripiprazole (25), 1.25–15 mg/day G3: No medication (25) | G1: 11.2±3.1 yr/Male: 92%/White: NR G2: 11.6 ±2.2 yr/Male: 88%/White: NR G3: 10.2±2.8 yr/Male: 88%/White: NR Comorbidities: ADHD (10), OCD (20) | Tourette syndrome (75) ROB: High (subjective), High (objective)
Bruggeman, 2001^164^ RCT, 12 wk Harms | G1: Pimozide (24), 2.9 (1–6) mg/day G2: Risperidone (26), 3.8 (0.5–6) mg/day | G1: NR (11–18)/Male: 87.5%/White: NR G2: NR (11–18)/Male: 88.5%/White: NR Comorbidities: ADHD (2), GAD (3), OCD (23) | Tourette syndrome (50) ROB: NA (subjective), Medium (objective)
Gilbert, 2004^166^ RCT (cross-over^*^), 4 wk | G1: Pimozide (7), 2.4 mg/day G2: Risperidone (12), 2.5 mg/day | All groups: NR/Male: NR/White: NR Comorbidities: ADHD (7), CD (1), learning disorder (3), OCD (2), ODD (2) | Chronic tic disorder (3), Tourette syndrome (16) ROB: High (subjective), High (objective)
SGAs vs. SGAs
Ghanizadeh, 2014b^165^ RCT, 8 wk | G1: Aripiprazole (31), 4.0±2.4 mg/day G2: Risperidone (29), 0.6±0.2 mg/day | G1: 11.12±3.3 yr/Male: 82.8%/White: NR G2: 10.22±2.3 yr/Male: 86.2%/White: NR Comorbidities: ADHD (4) | Tic disorder (60) ROB: High (subjective), High (objective)
FGAs vs. FGAs
Sallee, 1997^168^ RCT (cross-over), 6 wk | G1: Haloperidol (22)^*^, 3.5±2.2 mg/day G2: Pimozide (22)^*^, 3.4±1.6 mg/day G3: Placebo (22)^*^ | All groups: 10.2±2.5 yr/Male: 77%/White: NR Comorbidities: ADHD (13), OCD (5) | Tourette’s syndrome (22) ROB: High (subjective), High (objective)
Sallee, 1994^169^ RCT, 6 wk | G1: Haloperidol (17), 1.5±0.6 mg/day G2: Pimozide (24), 3.7±1.4 mg/day G3: No medication (25) | G1: 10.4 yr/Male: 90%/White: NR G2: 10.8 yr/Male: 90%/White: NR G3: 10.8 yr/Male: 90%/White: NR Comorbidities: ADHD (22) | Tourettte’s syndrome (66) ROB: Medium (subjective), Medium (objective)
FGAs vs. Placebo
Sehgal, 1999^171^ RCT, 8 mo | G1: Pimozide (6), 3.5 mg/day G2: Placebo (4) | All groups: 10 yr/Male: 80%/White: NR Comorbidities: NR | Tourette’s syndrome (10) ROB: Medium (subjective), NA (objective)
SGAs vs. Placebo
Yoo, 2013^172^ RCT, 10 wk | G1: Aripiprazole (32), 11.0±6.1 mg/day G2: Placebo (29) | G1: 11±2.5 yr/Male: 93.8%/White: NR G2: 10.9±3.0 yr/Male: 79.3%/White: NR Comorbidities: ADHD (6), ODD (3), anxiety disorder (1) | Tourette’s syndrome (61) ROB: High (subjective), High (objective)
Scahill, 2003^170^ RCT, 8 wk | G1: Risperidone (12), 2.5±0.9 mg/day G2: Placebo (14) | All groups: 11.1±2.2/Male: 96%/White: NR Comorbidities: ADHD (11), OCD (4) | Tourette’s syndrome (26) ROB: Medium (subjective), Medium (objective)
Sallee, 2000^167^ RCT, 8 wk | G1: Ziprasidone (16), 28.2±9.6 mg/day G2: Placebo (12) | G1: 11.3 yr/Male: 87.5%/White: NR G2: 11.8 yr/Male: 66.7%/White: NR Comorbidities: ADHD (15), DBD (5), learning disability (2), OCD (10) | Tourette’s syndrome (27) ROB: Medium (subjective), Medium (objective)

ADHD = attention deficit hyperactivity disorder; CD = conduct disorder; DBD = disruptive behavior disorder; FGA = first-generation antipsychotic; G = group; mg = milligrams; mo = month; N = number; NR = not reported; NRCT = nonrandomized controlled trial; OCD = obsessive-compulsive disorder; ODD = oppositional defiant disorder; RCT = randomized controlled trial; ROB = risk of bias; SD = standard deviation; SGA = second-generation antipsychotic; wk = week

* All patients experienced each of the treatment arms in this cross-over study

Patients enrolled in the studies had an average age of 10.7 years and were predominantly male (84 percent). The distribution of patient ethnicity was not reported in any of the studies. All but one study^175^ enrolled patients with Tourette’s syndrome. Patients had a variety of comorbidities, including ADHD (34%); OCD (23%); and DICD (5%). Only one study permitted concomitant psychotropic medications including stimulants.^165^

Two studies examining benefit outcomes compared an FGA with an SGA: pimozide versus risperidone,^166^ and haloperidol versus aripiprazole.^175^ Three other studies reporting on harms only compared pimozide with risperidone^164^ and with aripiprazole.^173, 174^ One RCT^165^ compared an SGA (risperidone) with another SGA (aripiprazole). Two studies^168, 169^ provided data on the comparative effectiveness of two FGAs, haloperidol and pimozide. A placebo-controlled withdrawal study compared short-term and long-term outcomes of treatment with pimozide.^171^ Two trials compared SGAs risperidone^170^ and ziprasidone^167^ with placebo.

Two of the RCTs had a cross-over design.^166, 168^ Three studies examined treatment durations of longer than 6 months.^171, 173, 174^ Of the short-term studies, average duration of treatment was 7.7 weeks (range 4 to 11.2 weeks). Fifty percent of studies had high risk of bias, mainly due to incomplete outcome data (RCTs) or lack of randomization and blinding (NRCTs).

### Tic Disorders: Intermediate Outcomes

Eight studies reported on the effects of FGAs and SGAs on treating intermediate outcomes of children with tic disorders.^165–170, 172, 175^ A summary of the key points by comparison is presented below. Strength of evidence grades for all key outcomes that were graded as having at least low SOE are provided in Table 25.

Table 25 Strength of evidence for tic disorders: Key intermediate outcomes having at least low strength of evidence

Comparison | Outcome (N Studies; N Patients) | Findings,^a^ Studies, and Tool With Range of Values | Strength of Evidence; Conclusions
SGAs vs. placebo | Tic severity (3, 114) | MD, −6.26; 95% CrI, −10.05 to −2.54^167, 170, 172^ YGTSS Total Tic score (range 0–50) | Low; SGAs may decrease^b^

CrI = credible interval; N = number; MD = mean difference; ROB = risk of bias; SGA = second-generation antipsychotic; YGTSS = Yale Global Tic Severity Scale.

a A negative MD score favors the SGAs. This MD of 6 points is considered clinically meaningful.

b Downgraded for ROB and imprecision because of small sample size (typically < 200 patients).

#### Key Points

- FGAs versus SGAs (one RCT^166^ and one NRCT^175^): Tic severity and clinician ratings of global improvement were examined for risperidone versus pimozide^166^ and aripiprazole versus haloperidol;^175^ the aripiprazole comparison also reported on global impressions of severity. Because of ROB and imprecision, we had no confidence in the findings to support any conclusions.
- Haloperidol versus pimozide (two RCTs^168, 169^): The effects between haloperidol and pimozide are not known in terms of tic severity, global impressions of severity or functioning,^168^ or school performance.^169^
- Risperidone versus aripiprazole (one RCT^165^): It is not known if there is any difference between risperidone and aripiprazole for tic severity, response rates, or school performance.
- FGAs versus placebo/no treatment (two RCTs^168, 169^): Our confidence was very low for making any conclusions on effects of haloperidol or pimozide versus placebo for tic severity, response rates, or ratings on global improvement and functioning.^168^ The effects of pimozide and haloperidol versus no treatment for school performance, learning, and total academic function are not known.^169^
- SGAs versus placebo (three RCTs [aripiprazole,^172^ risperidone,^170^ ziprasidone^167^]): Tic severity may be reduced in patients receiving SGAs. Effects for response, using global impression ratings, from risperidone and aripiprazole are unknown. In terms of overall tic disorder severity (rated using CGI-I scores), the effects from studies of aripiprazole and ziprasidone provided us with too little confidence to make conclusions. The SOE for response rates and global impression of severity scores was considered insufficient due to ROB, inconsistency (response), and imprecision (response and severity). Observations on between-study subgroup effects: (a) the study enrolling the fewest patients with comorbid ADHD was that of aripiprazole,^172^ although there is no suggestion of a differential effect in this study from the others, (b) observations related to concomitant stimulant use cannot be drawn; only one study^165^ allowed for concomitant stimulant medication and the rate of stimulant use was low (2 patients per group).

#### Detailed Analysis

##### FGAs Versus SGAs

Pimozide versus risperidone. A crossover RCT compared the effectiveness of pimozide and risperidone in children ages 7 to 17 years.^166^ The study duration was 8 weeks, and patients received each drug for 4 weeks. Risperidone was significantly more effective than pimozide at reducing the total score (p = 0.05), but not the total tic subscale (p = 0.25; Figure 76), on the Yale Global Tic Severity Scale (YGTSS); risperidone appeared favorable to pimozide for parent reports of tic severity on the Tic Symptom Self-Report but the difference did not reach statistical significance (p = 0.06). No significant differences between the groups were observed for global impressions of improvement on the CGI-I (p = 0.43).

Figure 76 FGAs versus SGAs for tic severity using YGTSS Total Tic score in tic disorders

FGA = first-generation antipsychotic; SD = standard deviation; SGA = second-generation antipsychotic; YGTSS = Yale Global Tic Severity Score

Figure 76 displays a meta-graph of studies reporting the effectiveness of FGAs versus SGAs for tic severity in tic disorders using the YGTSS total tic subscale. Our meta-graph showed Risperidone was not more effective than Pimozide at reducing the YGTSS (1 trial, 19 subjects; MD, −3.20; 95% CI, −8.70, 2.30). Similar results for Ariprazole versus Haloperidol (1 trial, 48 subjects) show the difference between groups was not statistically significant (MD, 3.10; 95% CI −0.95, 7.15).

Haloperidol versus aripiprazole. An 8-week NRCT comparing haloperidol with aripiprazole found no difference between groups for tic severity using the total tic score on the YGTSS (Figure 76).^175^ The proportion of patients with scores of 1 (“very much improved”) or 2 (“much improved”) on the CGI-I for global impressions of improvement did not differ between groups (p = 0.42); no difference was found between groups for global impressions of severity on the CGI-S (data not reported). One patient in each group reported an increase in appetite.

##### FGAs Versus FGAs

Haloperidol versus pimozide. Two RCTs compared the effect of haloperidol and pimozide for intermediate outcomes in children ages 7 to 16 with Tourette syndrome. In a cross-over study with 6 weeks of treatment with each medication, Sallee et al.^168^ found no significant differences between groups for tic severity using the tic subscales on the Tourette Syndrome Global Scale (TSGS) (p = 0.4) or the Tourette’s Syndrome Symptom List (p = 0.64), or for global impressions of severity (CGI–S; p = 1.0) or functioning (C-GAS; p = 0.51). Treatment adherence was high in both groups, with no significant difference.

A second RCT by Sallee et al.^169^ randomized patients to haloperidol, pimozide, or no medication for 8 weeks. Patients were assessed using the school performance, working hard, learning, and function subscales of the Child Behavior Checklist–Teacher Report Form. The pimozide group showed significantly greater improvement on the working hard subscale compared with the haloperidol group (p < 0.05). No significant differences were found between the groups for any of the other subscales.

##### SGAs Versus SGAs

An 8-week RCT^165^ compared risperidone and aripiprazole for intermediate outcomes. No differences were found between groups for tic severity (YGTSS Total Tic score; p = 0.5), response rates (79.3% vs. 90.3%; p = 0.2), or for school performance using parent reports on educational functioning via the Pediatric Quality of Life Inventory (p = 0.67). Eight patients in each group (N = 29 and 31) reported an increase in appetite.

##### FGAs Versus Placebo/No Treatment

In the crossover RCT comparing haloperidol and pimozide with placebo,^168^ tic severity on the TSGS significantly improved compared with placebo for the pimozide (p = 0.005) but not haloperidol (p = 0.07) group. Both groups had a better response rate (70% reduction in tic severity) than did the placebo group (haloperidol, p = 0.02; pimozide, p = 0.009). Both FGAs were superior to placebo for global impressions of severity (CGI-S, p = 0.01) and functioning (C-GAS, p < 0.05).

In the RCT^169^ comparing haloperidol, pimozide, and no medication, pimozide was similar but haloperidol was inferior to the no medication group on the subscales of working hard, learning, and total academic function (all p < 0.05) using the Child Behavior Checklist–Teacher Report Form.

##### SGAs Versus Placebo

Three placebo-controlled RCTs evaluated SGAs: aripiprazole,^172^ risperidone,^170^ and ziprasidone.^167^ The trials were between 8 and 10 weeks duration, and studied patients about 11 years of age with Tourette’s Syndrome.

Short-term core symptoms. A meta-analysis was conducted using data from all three RCTs on tic severity using the YGTSS Total Tic subscale (Figure 77). Tic severity was significantly reduced by SGAs compared with placebo (MD, −6.26; 95% CrI, −10.05 to −2.54); the magnitude of the mean difference is considered clinically meaningful.^176^

Figure 77 SGAs versus placebo for tic severity using YGTSS Total Tic score in tic disorders

CrI = credible interval; MD = mean difference; SD = standard deviation; SGA = second-generation antipsychotic; YGTSS = Yale Global Tic Severity Scale

Figure 77 displays a forest plot of studies reporting the mean difference of SGAs versus placebo for tic severity in tic disorders using YGTSS Total Tic score. Our meta-analysis (3 trials, 115 subjects) showed a clinically meaningful reduction in tic severity with use of SGAs versus placebo (MD, −6.26; 95% CrI, −10.05 to −2.54; I2=0%).

Short-term nonspecific symptoms. Obsessive-compulsive symptoms improved significantly in the ziprasidone group compared with placebo (CY-BOCS, p = 0.0003).^167^ Response rates were reported by two RCTs (Figure 78).^170, 172^ Using final scores of 1 or 2 on the Tourette’s Syndrome CGI-I scale, aripiprazole did not differ from placebo for response (66 vs. 45 percent; p = 0.09).^172^ Using similar scoring on the generic CGI-I, Scahill et al.^170^ found greater response for risperidone versus placebo (75% vs. 7%; p = 0.02).

Figure 78 SGAs versus placebo for response rates in tic disorders

SGA = second-generation antipsychotic

Figure 78 displays a meta-graph of studies reporting the mean difference of SGAs versus placebo for response rates in tic disorders. The figure showed that Risperidone (1 trial, 26 subjects) had a greater response than placebo on the generic CGI-I (RR, 10.5; 95% CI, 1.54, 71.38). On a Tourette’s syndrome CGI-I scale Aripiprazole (1 trial, 61 subjects) did not differ in response from placebo (RR, 1.51; 95% CI, 0.94, 2.42).

Short-term global impressions. Two RCTs^167, 172^ measured global impressions of severity using the Tourette’s Syndrome CGI-S scale; both aripiprazole (p = 0.03)^172^ and ziprasidone (p = 0.1)^167^ reduced severity relative to placebo by about 0.7 points, although only the finding for aripiprazole was statistically significant (Figure 79).

Figure 79 SGAs versus placebo for global impressions of severity using Tourette’s Syndrome CGI-S in tic disorders

CGI-S = Clinical Global Impressions of Severity; SD = standard deviation; SGA = second-generation antipsychotic

Figure 79 displays a meta-graph of studies reporting the mean difference of SGAs versus placebo for global impressions of severity using Tourette’s Syndrome CGI-S in tic disorders. Our meta-graph showed that both Aripiprazole (1 trial, 61 subjects; MD, −0.60; 95% CI, −1.19 to −0.01) reduced severity relative to placebo. For Ziprasidone (1 trial, 28 subjects; MD, −0.70; 95%CI, −1.42 to 0.02) there was no statistically significant difference between groups.

Lifestyle behaviors. One RCT^172^ comparing aripiprazole with placebo reported on lifestyle behaviors in terms of appetite increase. Two of 32 patients receiving aripiprazole versus zero of 28 patients on placebo reported increases in appetite (p = 0.33).

###### Observations on Between-Study Subgroup Effects

All comparisons had few studies making any observations of differential effects for certain subgroups difficult. The two RCTs^165, 172^ having the fewest patients with comorbid ADHD both studied aripiprazole, although the effects of this antipsychotic do not seem to differ from others. Observations related to concomitant stimulant use cannot be drawn; only one study^165^ allowed for concomitant stimulant medication and the rate of stimulant use was low (2 patients per group).

### Tic Disorders: Effectiveness Outcomes

Three RCTs^165, 169, 171^ assessed the use of antipsychotics for treating effectiveness outcomes in tic disorders. One RCT^171^ examined long-term effectiveness of placebo-controlled discontinuation of pimozide for exacerbation of tics. Below is a summary of the key findings by outcome. Strength of evidence was insufficient to draw conclusions for any comparisons or outcomes.

#### Key Points

- FGAs versus FGAs (one RCT^169^): The effects of pimozide compared with haloperidol for cognitive effects are not known.^169^
- SGAs versus FGAs (one RCT^165^): It is not known if risperidone and aripiprazole differ in their effects on social, emotional, or physical functioning.
- FGAs versus placebo (one RCT^171^): For long-term treatment with pimozide versus placebo, the relative effects on response are unknown.

#### Detailed Analysis

Long-term nonspecific symptoms. One RCT^171^ compared 8-month treatment with pimozide with discontinuation using placebo after at least 6 weeks of response on pimozide. Patients receiving long-term treatment had a longer time until dose increases were required to treat tic exacerbation (231 vs. 37 days; p = 0.02).

Cognitive and emotional development. One RCT comparing haloperidol and pimozide with a no medication treatment control group found significantly fewer commission errors on a continuous performance task in the pimozide compared with haloperidol and no medication groups.^169^ Results for omission errors and memory processing efficiency (memory search task) were no different between groups.

Quality of life. Ghanizadeh et al.^165^ compared aripiprazole with risperidone for measures of quality of life using a Farsi version of the parent-rated Children’s Quality of Life Inventory. The group receiving risperidone experienced greater increases in social functioning than did the aripiprazole group (p = 0.03), although their baseline scores were lower. No differences between groups were found for the domains of emotional or physical functioning.

### Tic Disorders: Within-Study Subgroup Effects

Only one study performed relevant subgroup analysis (Table 26). Sallee et al.^169^ found that the preferential effect by pimozide versus haloperidol for reducing commission errors was only present in the sample of patients having comorbid ADHD. In this subsample, haloperidol was associated with significantly higher commission errors. The authors comment on the relatively low doses of pimozide in their study compared with other studies, which may have improved the beneficial effect on cognition.

Table 26 Within-study analysis for subgroup effects in tic disorders

Author, Year, Comparison | Type of Analysis | Outcome | Authors’ Conclusions
Sallee, 1994^169^ Haloperidol vs. pimozide | Regression analysis by comorbidity | CPT task commission and omission errors | Patients with ADHD had significantly higher commission and omission errors than patients without ADHD.

ADHD = attention deficit hyperactivity disorder; CPT = continuous performance task

### Behavioral Issues: Overview

Two 4-week RCTs^177, 178^ compared risperidone with placebo for treatment of behavioral issues in children without psychiatric diagnoses within the categories of this review. The inclusion criteria in one study^178^were persistent behavioral disturbances (e.g., hostility, aggressiveness, irritability, agitation) in children with intellectual impairment and living in residential homes. The other study^177^ focused on children diagnosed clinically with a masturbation problem. Table 27 and Appendix D contain details on the study characteristics.

Table 27 Characteristics of trials examining behavioral issues

First Author, Year Study Design, Duration | Intervention (N Enrolled), Dosage (mg/day) Mean±SD | Age, Mean±SD (range)/Males (%)/White (%) Comorbidities | Diagnosis Breakdown (n) Quality Rating
SGAs vs. Placebo
Van Bellinghen, 2001^178^ RCT, 4 wk | G1: Risperidone (6), 1.2 mg/day G2: Placebo (7) | G1: 6–14 yrs/Male: 33%/White: NR G2: 6–14 yrs/Male: 43%/White: NR Comorbidities: NR | Behavioral disturbances and borderline intellectual functioning ROB: Medium (subjective), Medium (objective)
Omranifard, 2013^177^ RCT, 4 wk | G1: Risperidone (44), 0.25 −1 mg/day G2: No medication (46) | G1: 5.3±1.1 yr/Male: 52%/White: NR G2: 4.9±1.1 yr/Male: 58%/White: NR Comorbidities: NR | Habitual behavior (masturbation) ROB: High (subjective), NA (objective)

G = group; N = number; NA = not applicable; NR = not reported; SD = standard deviation; wk = week; yr = year

### Behavioral Issues: Intermediate Outcomes

Two RCTs^177, 178^ examined intermediate outcomes in children experiencing behavioral issues outside the context of a psychiatric disorder. A summary of findings for key outcomes is followed by details for all outcomes.

#### Key Points

- Risperidone versus placebo (one RCT^178^): All key outcomes were assessed as having insufficient SOE because of risk of bias, inconsistency, and imprecision.

#### Detailed Analysis

##### Risperidone Versus Placebo/No Medication

Van Bellinghen et al.^178^ found risperidone to significantly reduce symptoms of irritability (p < 0.05) and hyperactivity (p < 0.01), but not those of lethargy, stereotypic behavior, or inappropriate speech using the ABC. For global impressions, scores on the CGI-I improved by 2 points more for the risperidone group (p < 0.05), and 5 of 6 versus 0 of 6 patients were rated as “much or very much improved” by taking risperidone or placebo, respectively.

Risperidone reduced the frequency of masturbation compared with no medication in the study by Omranifard and colleagues^177^ (mean reduction by 1.6 vs. 1.2 times/day, p = 0.01).

## Key Question 2 Harms

This section reviews the evidence on harms for antipsychotic use in children and young adults (KQ2). The section begins by describing the studies not previously included in the sections for KQ1 on each condition; studies of patients having a variety of primary diagnoses (i.e., “mixed condition” studies) were included for data on harms but not for intermediate or effectiveness outcomes. We then describe findings on harms by comparison, beginning with findings across all comparisons, and followed by head-to-head and then placebo-controlled comparisons. Within each comparison, we begin with findings for major adverse effects (AEs) followed by general AEs, including our assessments of the SOE for key harms having at least low SOE. The section ends with findings from subgroup analyses.

There was a wide variety of possible harms on which to report. We made some decisions regarding which data to report and/or analyze for this report, based on harm category and clinical relevance. All data on our predefined major AEs are presented. For general AEs, we chose outcomes best aligning with our key harm outcomes (e.g., hypertriglyceridemia versus serum triglycerides to represent one feature of dyslipidemia). Also for general AEs, we only present data in the main report for findings on AEs limiting treatment (not undergoing SOE assessments but considered clinically relevant), and on other outcomes assessed as having at least low SOE. Insufficient SOE was often the result of ROB of the studies contributing data, and imprecision due to small sample sizes and/or confidence intervals (or credible intervals if meta-analysis was conducted) included clinically relevant effects despite an effect estimate of no difference. For rare outcomes (i.e., < 5%), the SOE was generally considered insufficient unless the sample size was large enough (2000 at minimum) to offer adequate prognostic balance to detect at least a small difference.^61^ Appendix G contains additional findings from the network meta-analysis (star plots, inconsistency tables, results for all possible comparisons), and all findings (absolute and relative effects) for general AEs.

### Mixed Condition Studies: Overview

Harms were reported in 126 studies (93%) included in this review. Of these, 1 trial^179^and 22 observational studies (11 prospective^180–190^ and 11 retrospective^191–201^) reported on harms data for children and young adults with mixed primary diagnoses. Table 28 provides details for the studies of mixed conditions; the studies enrolling patients having a primary diagnosis in one of our condition categories are described in the sections on KQ 1 for intermediate and effectiveness outcomes. Twelve of the mixed studies reported on harms after short-term (< 6 months) treatment (range 3 weeks to 3 months); eleven reported on treatment durations ≥ 6 months. Five of these studies focused exclusively on patients naïve to antipsychotic treatment. The average age of patients was 13.5 years, and 67 percent were male; of those reporting on race/ethnicity (N = 14), 66 percent of patients were reported as being white. Nineteen studies examined head-to-head comparisons between various SGAs, while four compared an SGA to a control group not receiving antipsychotics. The NRCT^179^ had high risk of bias. Of the observational studies, thirteen eceived a ROB rating of low (6–8 of 8 stars), 8 were of moderate ROB (4–5 stars), and one was considered of high ROB (3 stars).

Table 28 Characteristics of studies reporting on harms for mixed conditions

Author, Year, Study Design, Duration | Intervention (N Enrolled), Dosage (mg/day) Mean±SD | Age, Mean±SD (Range)/Males (%)/White (%) Comorbidities | Diagnosis Breakdown (n) Clinical Context Quality Rating
SGAs vs. SGAs
Alacqua, 2008^191^ Retrospective cohort, 3 mo | G1: Clozapine (2), 150±0.7mg/day G2: Olanzapine (24), 7.1±4.4mg/day G3: Quetiapine (2) 375±318.2mg/day G4: Risperidone (45), 2.0±1.3mg/day | G1: 15.5±0.7yr/Males: 50%/White: NR G2: 14.7±2.3yr/Males: 42%/White: NR G3: 16.5±1.5yr/Males: 100/White: NR G4: 13±3.9yr/Males: 80/White: NR Comorbidities: NR | ASD (15), CD (8), ADHD (1), psychosis (19), schizophrenia (5), TD (2), MR (11), anxiety (6) Incident treatment with atypical antipsychotics; outpatient/community History of treatment: 100% drug naive 6/8 stars
Arango, 2014^181^ Prospective cohort, 6 mo | G1: Risperidone (157), NR G2: Olanzapine (44), NR G3: Quetiapine (47), NR | G1: 14.0±3.3yr/Males: 64.3%/White: 84.7 G2: 15.4±1.8yr/Males: 63.6%/White: 93.2 G3: 15.7±1.6yr/Males: 53.2%/White: 89.4% Comorbidities: NR | Schizophrenia spectrum (84), mood spectrum disorders (72), behavioral disorders (47), other diagnosis (38) Inpatient/outpatient History of treatment: 39% drug naive 5/8 stars
Bastiaens, 2009^192^ Retrospective cohort, 2 mo | G1: Aripiprazole (24), 4.5±2.3mg/day G2: Ziprasidone (22), 42.9±18mg/day | G1: 11.7±2.4 yr/Male: 83%/White: NR G2: 12.1±2.9 yr/Male: 91%/White: NR Comorbidities: NR | BD (12), CD (14), depressive disorder (6), mood disorder NOS (8), PDD (2), psychotic disorder (4) Clinically significant aggressive behavior, outpatient/community History of treatment: 74% drug naive 6/8 stars
Calarge, 2014^182^ Prospective cohort, 6 mo follow up of 1.5 yr study | G1: Risperidone continued (74), 0.03±0.02 mg/kg/day G2: SGA continued (9), NR G3: SGA discontinued (18), NR | G1: 13.3±2.7 yr/Males: 95%/White: 80% G2: 12.3±2.6 yr/Males: 89%/White: 67% G3: 13.1±2.3 yr/Males: 89%/White: 94% Comorbidities: NR | DBD (89), ADHD (89), anxiety disorder (31), depressive disorder (5), ASD (19), tic disorder (25) History of treatment: 0% drug naïve 5/8 stars
Correll, 2009^183^ Prospective cohort, 2.8 mo | G1: Aripiprazole (47), NR G2: Olanzapine (52), NR G3: Quetiapine (45), NR G4: Risperidone (168), NR | G1: 13.4±3.1 (7–19.7) yr/Males: 56%/White: 62.5% G2: 14.7±3.2 (6.6–18.6) yr/Males: 64%/White: 46.7% G3: 14±3.1 (6.1–19.4) yr/Males: 36%/White: 50% G4: 13.6±4 (4.3–19.9) yr/Males: 62%/White: 46.3% Comorbidities: NR | ASD (21), CD/ODD (37), BD (44), MDD (49), mood disorder NOS (37), schizophrenia/schizoaffective (27), psychosis NOS (53) History of treatment: 100% drugnaïve 8/8 stars
Cuerda, 2011^184^ Prospective cohort, 1 yr | G1: Risperidone (18), NR G2: Olanzapine (12), NR G3: Quetiapine (16), NR | G1: 16.1±1.9 yr/Males: 83.3%/White: 72.2% G2: 16.1±1.3 yr/Males: 66.7%/White: 91.7% G3: 16.6±0.7 yr/Males: 62.5%/White: 81.3% Comorbidities: NR | BD (7), brief psychosis/schizophrenia (10), CD (4), depression with psychotic symptoms (3), OCD (3), psychosis NOS (11), schizophrenia (4), scholar phobia (1), depression (1), intellectual disability (1), personality disorder (1) History of treatment: 33% drugnaïve 6/8 stars
Findling, 2008b^185^ Prospective cohort, 3–4 wk | G1: Aripiprazole (8), low (20 mg/day fixed) G2: Aripiprazole (7) medium (25 mg/day fixed) G3: Aripiprazole (6) high (30 mg/day fixed) | All groups 10–17 yr (mean NR), Males: NR/White: NR Comorbidities: MR (0) | BD, DBD, OCD, ASD, schizophrenia, Tourette syndrome History of treatment: 100% drugnaïve 5/8 stars
Findling, 2015^179^ NRCT, 3 wk | G1: Lurasidone (20), 20mg/day G2: Lurasidone (25), 40mg/day G3: Lurasidone (19), 80mg/day G4: Lurasidone (25), 120mg/day G5: Lurasidone (16), 160mg/day | All groups 12.7 yr mean age, Males: 65%/White: 78% Comorbidities: NR | ADHD (78), BP (19), Schizophrenia (5), Tourette’s (2), ASD (1). Outpatient: History of treatment: NR drug naive ROB: NA (subjective), High (objective)
Fleischhaker, 2006^186^ Prospective cohort, 7.4 wk | G1: Clozapine (16) 321.9±156.5 (125–600) mg/day G2: Olanzapine (16), 16.6±7.1 (7.5–30) mg/day G3: Risperidone (19), 3.9±1.7 (1–6) mg/day | G1: 17.2±1.8 (14.4–21.3) yr/Males: 69%/White: NR G2: 15.8±1.4 (12.8–17.8) yr/Males: 56%/White: NR G3: 15.6±2.6 (9.7–19) yr/Males: 68%/White: NR Comorbidities: NR | anorexia nervosa, DBD, OCD, ASD, schizophrenia, Tourette syndrome Inpatient History of treatment: NR drug naive 3/8 stars
Fraguas, 2008^187^ Prospective cohort, 6 mo | G1: Olanzapine (25), 9.8±5.6mg/day G2: Quetiapine (29), 390.8±321.2mg/day G3: Risperidone (38), 3.5±3.1mg/day | G1: 15.9±1.5 (12–17) yr/Males: 65%/White: 90% G2: 16.3±1.3 (13–18) yr/Males: 58%/White 96% G3: 13.4±4 (4–17) yr/Males: 77%/White: 82% Comorbidities: NR | BD, DBD, ASD, schizophrenia History of drug treatment: 24% drugnaïve 6/8 stars
Friedlander, 2001^195^ Retrospective cohort, 6 wk | G1: Olanzapine (14), NR G2: : Risperidone (41), NR | All groups: 13–24 yr (mean NR)/males: NR/White: NR Comorbidities: Addison’s disease (1), hypothyroidism (4), MR (borderline (1), mild (17), moderate (15), severe (9)), Neurodevelopmental syndrome (15), Seizure disorder (9) | BD, DBD, OCD, ASD, schizophrenia-related, Tourette syndrome Developmental disabilities and complex psychiatric problems History of treatment: 0% drug naive 4/8 stars
Germano, 2014^188^ Prospective cohort, 2 mo | G1: Aripiprazole (29), 7.4±3.1mg/day G2: Risperidone (31), 1.5±1.0mg/day | All groups (G1–G2): 10.2±2.6 yr/Male: 91.6%/White: NR Comorbidities: NR | PDD (22), ODD (12), ADHD (21), MR with psychotic disorder (11), Tourette syndrome and other tic disorders (9) Subjects attending programs in a University Polyclinic History of treatment: 23% drug naive 5/8 stars
Jerrell, 2008^196^ Retrospective cohort, ≥9 mo | G1: Antipsychotics cohort (4140), 7.4±3.1mg/day Multiple logistic regressions with olanzapine (N = 326) as comparator, with aripiprazole (N = 38), ziprasidone (N = 87), quetiapine (N = 266), risperidone (N = 1634), multiple SGAs or SGA and FGA (N = 1756) | All groups: NR/Male: 68%/White: 42% Psychiatric comorbidities: SUD (489), ADHD (3259), CD (2269), neurotic, phobic or personality disorders (1668) Other comorbidities: Epilepsy (954), CNS disorders (919), organic brain syndrome or severe MR (704), congenital heart defects (146), endocrine disorder (168), preexisting obesity (680), preexisting type II diabetes mellitus or dyslipidemia (404), preexisting cardiovascular disorder (246) | Schizophrenia or other psychotic disorders (1507), major affective disorders (2261) Inpatient/outpatient History of treatment: NR drug naive 6/8 stars
Khan, 2006^198^ Retrospective cohort, 3.7–4.9 wk | G1: Olanzapine (50), total 8.2±2.4 mg/day, children 6±2.2 mg/day, adolescents 9.20±1.8 mg/day G2: Ziprasidone (50), total 19.1±2.7 mg/day, children 15.7±4.4 mg/day, adolescents 19.5±2.1 mg/day | G1: 13.7±2.4 yr/Males: 68%/White: 60% G2: 14.6±2.1 yr/Male: 32%/White: 68% Comorbidities: substance abuse/dependence (27), PTSD (18) | BD (57), mood disorder NOS (18), psychosis NOS (15). Agitation or aggression; inpatient History of treatment: NR drug naive 4/8 stars
Khan, 2009^197^ Retrospective cohort, olanzapine 27±12 d, risperidone 26±13 d | G1: Olanzapine (25), 12.5 (range 5–25 mg/day) G2: Risperidone (24), 2.6 (range 1–7 mg/day) | G1: 13.0±3.5 yr/Males: 64%/White: 72 G2: 13.0±3.5 yr/Males: 83%/White: 58 Comorbidities: SUD (14), ADHD (8) | BD (NR), mood disorder NOS (NR), major depressive disorder (NR), schizoaffective disorder, schizophrenia, and schizophreniform disorder (7) Inpatient History of treatment: NR drug naive 6/8 stars
Migliardi, 2009^200^ Retrospective cohort, 12 mo | G1: Olanzapine (13), 8.1mg/day G2: Risperidone (29), 1.8mg/day | G1: 14.1 yr/Males: 54%/White: NR G2: 10.7yr/Males: 79%/White: NR Comorbidities: NR | ASD, DBD, schizophrenia, bipolar, OCD, tic disorder Outpatient/community History of treatment: 100% drug naive 7/8 stars
Pogge, 2005^189^ Prospective cohort, 10 (3–18) mo | G1: Olanzapine (43), NR G2: Risperidone (43), NR | All groups (G1–G2): 14.9±1.3 yr/Male: 41.9%/White: 65.1% Comorbidities: NR | Psychotic (11), affective (30), anxiety (23), disruptive (57), PDD/MR (18), polysubstance (2), eating disorder Inpatient History of treatment: 0% drug naive 6/8 stars
Ronsley, 2015^180^ Prospective cohort, 12 mo | G1: Quetiapine (17), NR G2: Risperidone (20), NR | G1: 14.1 yr/Male: 47.1%/White: 52.9% G2: 14 yr/Male: 50%/White: 40% Comorbidites: NR | Psychotic disorders (9), mood disorder (4), depressive disorder (8), BD (6), ADHD(8), ODD(4), PDD (1), anxiety disorder(13), adjustment disorder(1), reactive attachment disorder (2) mental retardation or personality disorder(2) Outpatient History of treatment: 100% drug naive 4/8 Stars
Saito, 2004^190^ Prospective cohort, 11.2 wk | G1: Olanzapine (13), 7.8±4.2mg/day G2: Quetiapine (6), 283.3±222.9mg/day G3: Risperidone (21), 2.2±2mg/day | All groups: 13.4±3.4 (5–18) yr/Males: NR/White: NR Comorbidities: NR | schizophrenia or other psychosis (14), mood disorders (14), DBD (9), intermittent explosive disorder (1), PDD NOS (1), eating disorder NOS (1) History of treatment: NR drug naive 6/8 stars
SGAs vs. No Antipsychotic
Bobo, 2013^193^ Retrospective cohort, ≥1 yr | G1: Aripiprazole 5 (5–10) mg/day, olanzapine 5 (4.84–9) mg/day, quetiapine 53.57(50–100) mg/day, risperidone 0.75 (0.50–1) mg/day, perphenazine 4(2–6) mg/day, thioridazine 30 (20–50) mg/day, other/multiple 20 (2–50) mg/day (28858) G2: Controls not on antipsychotic for >365 days (14429), NR | G1: 14.5 yr/Male: 56%/White: 72.8% G2: 14.5 yr/Male: 55.9%/White: 73.5% Comorbidities: Menstruation absent or infrequent (1629), menstruation disorder (1486), diagnosed obesity (1658), metabolic disorder (909), blood chemistry panel with glucose (10154), hypertension (1110), other diagnosed cardiovascular disease (1904) | BD (7935), depression (8382), other mood disorder (14298), ADHD (16751), CD (10893), anxiety (8815), alcohol use (1370), other substance use (3909) Subjects enrolled in Medicaid; recent initiators of antipsychotics History of treatment: 0% drug naive 8/8 stars
Ebert, 2014^194^ Retrospective cohort, 4–53 wk (G1: 17±10.9 wk; G2: 9.7±6.1 wk) | G1: SGAs (32), NR G2: Controls with antipsychotic treatment (24), NR | G1: 9.6±1.6 yr/Male: 91.7%/White: NR G2: 9.3±1.8 yr/Male: 87.5%/White: NR Comorbidities: Anemia (1), ichthyosis (1), Epilepsy (1), central precocious puberty (1) | Psychotic spectrum disorder (15), BD (4), DBD (29), ADHD (26), anxiety spectrum disorder (8), depression disorder (13), PDD (5), MR (3), OCD (1), adjustment disorder (2), eating disorder (1), tic disorder (2) Inpatient History of treatment: NR drug naive 5/8 stars
Martin, 2000^199^ Retrospective cohort, ≥6 mo | G1: Risperidone (37), 2.8±1.9 mg/day G2: No SGA exposure (33), NR | G1: 12.5±2.4 yr/Male: 76%/White: 64 G2: 13.5±2.9 yr/Male: 49%/White: 61% Comorbidities: NR | Depressive disorder (37), mood disorder NOS (17), SUD (15), DBD (15), psychotic disorder (12), anxiety disorder (12), BP (10), ADHD (7), eating disorder (2) Inpatient History of treatment: NR drug naive 6/8 stars
Wonodi, 2007^201^ Retrospective cohort, ≥6 mo | G1: SGAs treatment ≥ 6mo (81), NR G2: No antipsychotic (80), NR | G1: 11.9±2.8 yr/Male: 77.1%/White: 44.1% G2: 10.7±3.9 yr/Male: 72.5%/White: 28.8% Comorbidities: NR | Mood disorder NOS (170), ADHD (123) Inpatient/outpatient History of treatment: 19% drug naïve 8/8 stars

ADHD = attention deficit hyperactivity disorder; ASD = autism spectrum disorder; BD = bipolar disorder; CD = conduct disorder; d = days; DBD = disruptive behavior disorder; G = group; FGA = first-generation antipsychotic; mg = milligram; mo = month; MR = mental retardation; N = number; NOS = not otherwise specified; NR = not reported; NRCT: nonrandomized controlled trial; OCD = obsessive-compulsive disorder; ODD = oppositional defiant disorder; PDD = pervasive developmental disorder; SUD= substance use disorder; SD = standard deviation; SGA = second-generation antipsychotic; wk = week; yr = year

### All Comparisons: Network Meta-Analyses for Body Composition Outcomes

We conducted network meta-analyses for the outcomes of weight and body mass index (BMI). These outcomes represent two of the key outcomes that were reported by the most studies (weight, N = 71; BMI, N = 35). To make our results most clinically relevant and be able to include as much data as possible, data was combined regardless of followup duration and (for those with multiple timepoints) from each study’s longest term followup; 14 studies for weight and 11 for BMI reported data for treatment durations 6 months or longer. As described in the methods chapter, network meta-analysis allows for simultaneous evaluation of a suite of comparisons (e.g., including placebo-controlled and head-to-head comparison) while still preserving the within-study randomization. Results are presented in terms of a placebo referent, to rank the drugs based on a common comparator, but data from head-to-head comparisons were incorporated in the analysis. Tables 29 (weight) and 30 (BMI) contain the results for each antipsychotic reporting on these outcomes, in terms of the studies included, sample size of the applicable study arms, and each drug’s relative effectiveness compared with placebo/no treatment (reference standard); the drugs are listed in order of their ranking in terms of having the most harm. It should be noted that the network approach accounts for direct and indirect comparisons such that other information contributes to the results. Figures 80 and 81 show plots of the findings. Appendix G contains the model, code, results of the diagnostic tests for consistency, and results for every possible comparison between the individual drugs. Key points for each analysis are presented, followed by a detailed analysis.

Table 29 Results from network meta-analysis for weight (kg) gain (reference standard placebo/no treatment)

Antipsychotic | Number of Studies, Citations | Total Sample Size | Mean Difference (kg) From Placebo | 95% Credible Interval | Probability of Being “Worst”
Molindone | 1^81^ | 20 | −0.68 | −7.29, 5.80 | 5.8%
Ziprasidone | 3^71, 116, 167^ | 246 | −0.10 | −1.25, 1.05 | 0.0%
Placebo | 44^71–73, 76, 86, 88, 90, 108–111, 114–121, 123, 125–129, 131, 132, 134, 135, 139, 147, 150–158, 167, 172, 178, 197^ | 1907 | 0 | NA | 0.0%
Thioridazine | 1^150^ | 15 | 0.13 | −1.71, 1.98 | 0.0%
Lurasidone | 1^127^ | 149 | 0.45 | −1.28, 2.19 | 0.0%
Pimozide | 2^164, 166^ | 26 | 0.71 | −8.87, 9.95 | 22.0%
Aripiprazole | 11^73, 94, 110, 117, 121, 123, 131, 135, 172, 175, 183^ | 869 | 0.88 | 0.26, 1.50 | 0.0%
Haloperidol | 6^77, 82, 99, 130, 133, 175^ | 72 | 0.97 | −0.43, 2.38 | 0.0%
Asenapine | 1^108^ | 302 | 1.12 | −0.65, 2.90 | 0.1%
Quetiapine | 12^67, 72, 109, 114, 115, 119, 155, 179, 180, 183, 184, 187^ | 655 | 1.25 | 0.51, 1.95 | 0.0%
Paliperidone | 2^90, 94^ | 261 | 1.72 | 0.36, 3.12 | 0.1%
Risperidone | 37^69, 79, 81, 82, 85, 88, 97, 99, 111, 113, 117, 125, 128, 129, 132–134, 139, 147, 151–154, 156–158, 164, 166, 178, 180, 181, 183, 184, 186, 187, 189, 199^ | 1535 | 1.85 | 1.40, 2.35 | 0.0%
Chlorpromazine | 1^66^ | 36 | 2.04 | −1.79, 5.85 | 10.5%
Clozapine | 6^77, 78, 80, 97, 98, 186^ | 72 | 2.38 | 0.37, 4.40 | 2.6%
Olanzapine | 22^66, 67, 69, 76, 78–82, 85, 86, 97–99, 113, 120, 126, 130, 179, 181, 182, 187^ | 611 | 4.12 | 3.43, 4.88 | 58.8%

kg =kilogram

Table 30 Results from network meta-analysis for increase in body mass index (BMI) (reference standard placebo/no treatment)

Antipsychotic | Number of Studies, Citations | Total Sample Size | Difference From Placebo (kg.m^−2^) | 95% Credible Interval | Probability of Being “Worst”
Haloperidol | 3^82, 96, 99^ | 33 | −0.42 | −1.46, 0.66 | 0.0%
Placebo | 17^73, 76, 88, 108, 111, 114, 117, 118, 120, 127, 128, 131, 135, 153, 157, 158, 172, 199^ | 967 | 0 | NA | 0.0%
Lurasidone | 1^127^ | 149 | 0.14 | 0.29, 0.57 | 0.0%
Molindone | 1^81^ | 20 | 0.30 | −2.06, 2.54 | 7.8%
Aripiprazole | 8^73, 94, 117, 131, 135, 144, 172, 183^ | 818 | 0.32 | 0.11, 0.55 | 0.0%
Quetiapine | 6^66, 101, 114, 180, 181, 187^ | 143 | 0.48 | 0.08, 0.78 | 0.0%
Asenapine | 1^108^ | 302 | 0.52 | 0.07, 0.98 | 0.0%
Risperidone | 21^68, 80–82, 88, 99, 101, 111, 118, 128, 144, 153, 157, 158, 180, 181, 183, 186, 187, 197, 199^ | 1138 | 0.59 | 0.40, 0.81 | 0.0%
Paliperidone | 1^94^ | 112 | 1.02 | 0.43, 1.62 | 1.5%
Olanzapine | 16^66, 69, 76, 78, 80–82, 96, 99, 101, 120, 181, 183, 186, 187, 197^ | 470 | 1.51 | 1.28, 1.84 | 21.2%
Clozapine | 2^78, 186^ | 28 | 1.96 | 0.55, 3.36 | 69.6%

Figure 80 Plot of network meta-analysis results for weight gain compared with reference standard (placebo/no treatment)

This plot shows the findings from a network meta-analysis combining placebo-controlled and head-to-head comparisons of first-generation and second-generation antipsychotics within one analysis. The effect shown represents the mean difference (kilograms [kg]) and credible intervals of each drug relative to placebo which was used as the reference standard.

Figure 80 is a plot of network meta-analysis results that compares weight gain for a variety of first and second generation antipsychotics to the reference of placebo/no treatment. The results are shown for both placebo-controlled and head-to-head comparisons, and show the effect and credible intervals of each drug compared to placebo. This figure is further described in the section “Detailed Analysis” as follows: “patients taking most antipsychotics gain more weight than patients not receiving antipsychotics. Patients taking molindone and ziprasidone may gain less weight on average whereas those receiving clozapine, olanzapine, and lurasidone may gain as much as 2 to over 4 kilograms more weight during treatment durations of a relatively short timeframe (81 percent of studies for this analysis were short-term which was often 6–12 weeks duration). Not all SGAs appear to contribute to more weight gain than FGAs; ziprasidone, pimozide, and aripiprazole led to less average weight gain than did haloperidol. The results for olanzapine clearly separated from those of other SGAs with the exception of clozapine and lurasidone.”

Figure 81 Plot of network meta-analysis results for increase in body mass index (BMI) compared with reference standard (placebo/no treatment)

This plot shows the findings from a network meta-analysis combining placebo-controlled and head-to-head comparisons of first-generation and second-generation antipscyhotics within one analysis. The effect shown represents the mean difference in BMI (kilograms per meter^−2^]) and credible intervals of each drug relative to placebo which was used as the reference standard.

Figure 81 displays a plot of network meta-analysis results comparing increase in body mass index (BMI) for a variety of first and second generation antipsychotics to the reference standard of placebo/no treatment. The results are shown for both placebo-controlled and head-to-head comparisons, and show the effect and credible intervals of each drug compared to placebo. This figure is further described in the section “Detailed Analysis” as follows: “changes in BMI were similar to those for weight gain. The FGAs appear to be relatively less harmful for BMI than for weight (e.g., haloperidol moved from sixth to first place in the rank order) but few studies and small samples contributed to the findings for FGAs. Olanzapine, clozapine, and lurasidone remained worst for average effect, although the results for clozapine and lurasidone are considerably imprecise.”

#### Key Points: Weight Gain Across Comparisons

- Not all SGAs appeared to contribute to more weight gain than FGAs.
- Results for olanzapine clearly separated this SGA as more harmful than most other SGAs. Results were most robust for the relative harm from olanzapine over aripiprazole, quetiapine, and risperidone.
- The magnitude of weight gain was generally applicable only to short-term treatment durations.

#### Key Points: Changes in BMI Across Comparisons

- Olanzapine and clozapine were more harmful than the other SGAs based on average effect, although the results for clozapine were considerably imprecise.

#### Detailed Analysis

Findings from our analysis for weight gain indicate that patients taking most antipsychotics gain more weight than patients not receiving antipsychotics (Table 29 and Figure 80). Patients taking molindone and ziprasidone may gain less weight on average whereas those receiving olanzapine may gain as much as 5 kilograms during treatment durations of a relatively short timeframe (81% of studies for this analysis were short-term which was often 6–12 weeks duration). Not all SGAs appear to contribute to more weight gain than FGAs; ziprasidone, pimozide, and aripiprazole led to less average weight gain than did haloperidol.

Some of the antipsychotics, particularly for the FGAs, had few patients contributing data to the findings, which resulted in wide credible intervals; for instance, the results for pimozide, molindone, chlorpromazine, and lurasidone were considerably more imprecise than those for other antipsychotics. The relative harm from olanzapine is most robust compared with aripiprazole, quetiapine, and risperidone because of the precision in these estimates from larger sample sizes.

Results of the network meta-analysis for changes in BMI were similar to those for weight gain (Table 30). The FGAs appear to be relatively less harmful for BMI than for weight (e.g., haloperidol moved from ninth to last place for being worst) but few studies and small samples contributed to the findings for FGAs. Olanzapine, and clozapine were worst for average effect, although the results for clozapine are considerably imprecise. Seventy-one percent of studies had short-term treatment durations.

The network analyses were reasonably consistent (Appendix G). A closed loop analysis showed that only 1 out of 15 triangular loops showed statistically significant inconsistency for the BMI analysis, while none of 18 loops showed significant inconsistency in the analysis of weight.

### FGAs Versus SGAs

Findings for major and general AEs reported by studies comparing FGAs and SGAs are described below. Short- and long-term results are presented separately. Nine studies reported on major (4 long-term duration) and 16 reported on general AEs (2 long-term duration).

#### Key Points: Major AEs

- Few studies having small sample sizes reported on these rare outcomes.
- Based on this review with insufficient SOE for all major AE outcomes, the effects between FGAs and SGA for various major AEs are not known.

#### Key Points: General AEs

- FGAs probably cause lower gains in weight and BMI than SGAs.
- Compared with FGAs, SGAs may decrease the risk for experiencing any EPS symptom.
- The class of antipsychotic may make little or no difference for sedation.
- We could not make conclusions for other outcomes (e.g., akathisia, dystonia, hyperprolactinemia); SOE was insufficient because of ROB and imprecision due to small samples sizes for these rare events.

#### Detailed Analysis

##### Major AEs During Short-Term (< 6 Months) Treatment

Major AEs and major AEs limiting treatment. One RCT^81^ (N = 116) reported on major AEs in comparisons between molindone, risperidone, and olanzapine in early-onset schizophrenia; two patients in the molindone and olanzapine groups, and four patients in the risperidone group experienced serious AEs. There was data from two RCTs^77, 82^ (N = 71) on serious AEs limiting treatment in children with schizophrenia, from comparisons between haloperidol and clozapine (1 vs. 3 events, respectively),^77^ olanzapine (2 vs. 0 events),^82^ and risperidone (2 vs. 0 events).^82^ One RCT^68^ (N = 74) reported on major AEs limiting treatment in a comparison between chlorpromazine and olanzapine (3 vs. 2 events) in first episode psychotic bipolar mania.

Neuroleptic malignant syndrome. In an RCT^77^ (N = 21) comparing haloperidol with clozapine in childhood-onset schizophrenia, one patient in the haloperidol group developed neuroleptic malignant syndrome.

Seizures. From data reported in one RCT^77^ (N = 21) comparing haloperidol with clozapine, and an observational study^99^ (N = 50) comparing haloperidol, olanzapine, and risperidone for treating schizophrenia, two patients in the clozapine group of one study experienced seizures while another three required prophylactic anticonvulsant treatment.

Cardiac arrhythmias. No patient with ASD experienced QT interval prolongation in a comparison (N =12) between haloperidol and olanzapine.^130^

Agranulocytosis and related effects. One RCT^77^ (N = 21) comparing haloperidol with clozapine in childhood onset schizophrenia reported that five patients taking clozapine experienced neutropenia, two of whom did not have spontaneous normalization. Another RCT^66^ (N = 74) comparing chlorpromazine with olanzapine in young adults with first episode psychotic mania had one patient in the olanzapine group who developed neutropenia.

##### Major AEs During Long-Term (≥ 6 Months) Treatment

Major AEs and major AEs limiting treatment. No patient experienced a major AE in one 6-month study^133^ (N = 28) comparing haloperidol with risperidone in autism spectrum disorder (ASD).

Development of diabetes mellitus. A prospective cohort study^102^ evaluated incidence of diabetes in early-onset schizophrenia for patients receiving haloperidol, clozapine, olanzapine, quetiapine, and risperidone during up to 5 year followup (N = 111). One patient receiving clozapine developed diabetes at 2 years.

Tardive dyskinesia. In a long-term extension (N = 54) comparing molindone, olanzapine, and risperidone in early-onset schizophrenia, no patient developed tardive dyskinesia.^81^

Cardiac arrhythmias. A dramatic QTc interval prolongation occurred after 6 months in one child taking pimozide in an NRCT^173^ (N = 50) comparing this drug with aripiprazole in tic disorders. No patient in either group had echocardiographic (ECG) modification.

###### General AEs During Short- and Long-Term Treatment

Table 31 summarizes the findings from short-term studies for general AEs that provided at least low SOE; the footnotes for the table describe the SOE assessments. For the outcome of any AE limiting treatment, our meta-analysis found no significant difference between FGAs and SGAs over the short-term (6 studies, 343 patients; RR, 1.78; 95% CrI, 0.96 to 3.62)^66, 81, 82, 175^ or at 12 months or longer duration (5 studies, 234 patients; RR, 0.42; 95% CrI, 0.11 to 1.19)^80, 101^ Several other outcomes (e.g., hyperprolactinemia, hypertriglyceridemia) were reported by single studies or by two very small studies; findings for individual drug comparisons were all reported by few and small studies. The findings for all outcomes are presented in Appendix G

Table 31 Summary of findings for general adverse effects: Short-term durations of FGAs versus SGAs

Outcome | N Studies, N Patients | FGA Events | FGA N | SGA Events | SGA N | Relative Effects^a^, Studies | Strength of Evidence; Conclusions
Any EPS | 4, 110 | 16 | 37 | 13 | 73 | RR, 2.59; 95% CrI, 1.00 to 7.00^99, 130, 172^ | Low; SGAs may decrease risk^b^
Weight (kg) | 14, 506 | NA | 190 | NA | 316 | MD, −2.62; 95% CrI, −4.35 to −0.86 ^66, 77, 81, 82, 99, 130, 133, 164, 166, 175, 194^ | Moderate; FGAs probably better^c^
BMI (kg·m^−2^) | 7, 236 | NA | 73 | NA | 163 | MD, −1.57; 95% CrI, −2.49 to −0.53^81, 82, 96, 99^ | Moderate; FGAs probably better^c^
Sedation | 7, 345 | 70 | 160 | 79 | 185 | RR, 1.04; 95% CrI, 0.86 to 1.37 ^66, 81, 82, 99^ | Low; may make little or no difference^d^

AE = adverse effect; BMI = body mass index; CrI = credible interval; FGA = first-generation antipsychotic; G = group; kg = kilogram; m = meter; MD = mean difference; N = number; RR = risk ratio; SGA = second-generation antipsychotic

a Risk ratios above 1.0 and positive MD favor SGAs.

b Downgraded for ROB and imprecision, based on small sample size.

c Downgraded for ROB.

d Downgraded for ROB and imprecision, because CrI includes possibility for clinically relevant benefit for SGAs.

### FGAs Versus FGAs

Findings for major and general AEs in comparisons between two or more different FGAs, or different doses of an FGA, are presented below. Two short-term RCTs^148, 168^ reported on major AEs. Two RCTs reported on a small number of general AEs; one short-term study compared haloperidol with pimozide,^168^ and a 6-month study compared continuous versus discontinuous (i.e., 5 days per week) haloperidol.^136^

#### Key Points

- There was insufficient SOE for all major and general AEs in comparisons between different FGAs or different doses of the same FGA; the effects are unknown.

#### Detailed Analysis

##### Major AEs During Short-Term (< 6 Months) Treatment

Major AEs and major AEs limiting treatment. One RCT^168^ (N = 44) reported on the number of patients with tic disorders who experienced major AEs in a comparison between haloperidol and pimozide (2 vs. 0 events, respectively).

Mortality. No child (6–12 years) died in a 9–12 week RCT^148^ (N = 78) comparing four doses of molindone for treatment of serious conduct problems in ADHD.

##### General AEs During Short- or Long-Term Treatment

No findings for general AEs in comparisons of FGAs versus FGAs had low or greater SOE. Single studies reported data for a small number of outcomes within the short- and long-term duration categories. Any AE limiting treatment was reported in a comparison between haloperidol and pimozide; 9 of 22 patients on haloperidol and 3 of 22 on pimozide discontinued treatment because of AEs.^168^ In a comparison of four different doses of molindone for treatment of ADHD, the incidence of AEs including changes to body composition seemed to increase with increasing dose although no statistical data was provided by the authors.^148^ Data for outcomes with insufficient SOE are presented in Appendix G.

### SGAs Versus SGAs: Comparison of Different Drugs

Findings by duration category for major and general AEs in comparisons between two or more SGAs are presented below. Sixteen (5 long-term) and 37 (13 long-term) studies reported on major and general AEs, respectively.

#### Key Points: Major AEs

- Aripiprazole (hazard ratio (HR) vs. no antipsychotic 7.72, 95% CI 3.70 to 16.12) may increase the risk for developing diabetes compared with risperidone (HR 2.20, 95% CI 1.14 to 4.26) (low SOE).
- Data for other rare AEs was mostly from single studies having small sample sizes and moderate or higher ROB, therefore SOE was deemed insufficient.

#### Key Points: General AEs

- Body composition. Risperidone probably decreases slightly gains in weight (short-term) and BMI changes (short-and long-term) compared with olanzapine; similar findings were found for quetiapine versus olanzapine over the long- but not short-term where there may be little or no difference. There may be little or no difference between weight gains caused by olanzapine and clozapine over short-term treatment. Quetiapine and risperidone are probably of little or no difference for short-term changes in BMI and 7 percent or greater increase in weight, and may be of little or no difference for BMI changes or weight gain over the long-term. For 7 percent or greater gain in body weight, there may be little or no difference between olanzapine and quetiapine, or olanzapine and risperidone.
- Hyperprolactinemia. Quetiapine may decrease the risk for hyperprolactinemia compared with risperidone.
- Sedation. There may be little or no difference between olanzapine and risperidone for risk of sedation.

#### Detailed Analysis

##### Major AEs During Short-Term (< 6 Months) Treatment

Major AEs and major AEs limiting treatment. Two RCTs reported on short-term experience of major AEs in treatment of schizophrenia: one compared aripiprazole and paliperidone (N = 228) with each associated with seven major AEs,^94^ and the other compared olanzapine and risperidone (N = 76) with two versus four patients having major AEs.^81^ Three RCTs^78, 124, 165^ reported on numbers of patients discontinuing SGA treatment because of major AEs. Four patients in each of groups receiving aripiprazole or risperidone in two RCTs of ASD and tic disorders (N = 116) had treatment-limiting major AEs.^124, 165^ Four patients on clozapine versus one patient on olanzapine had treatment-limiting major AEs in the other study of childhood schizophrenia.^78^

Mortality. Mortality rates (n = 0) were reported in one RCT (N =228) of aripiprazole or paliperidone treatment in schizophrenia.^94^

Development of diabetes mellitus. In an RCT^78^ (N = 39) comparing clozapine with olanzapine, one patient taking clozapine developed drug-induced diabetes at 12-weeks, and another patient on this drug was withdrawn for impaired glucose tolerance.

Seizures. Incidence of seizures was reported by four short-term studies.^80, 85, 99, 124^ One patient with ASD treated with aripiprazole versus none on risperidone (N = 56) had one or more seizures.^124^ No patients with schizophrenia on clozapine or olanzapine (N = 25) had seizures,^80^ and one patient receiving risperidone versus none taking olanzapine had seizures in the two studies (N = 78) examining this comparison among patients with schizophrenia.^85, 99^

Tardive dyskinesia. Two studies^85, 186^ reported on incidence of tardive dyskinesias over three drug comparisons. In the observational study (N = 51) of mixed conditions by Fleischhaker et al.,^186^ there were no cases of tardive dyskinesia in groups taking clozapine, risperidone, and olanzapine. No patient with schizophrenia receiving risperidone or olanzapine developed tardive dyskinesia in another study (N = 44).^85^

Cardiac arrhythmias. Four studies reported on short-term outcomes related to cardiac arrhythmias over different drug comparisons in patients with bipolar disorder,^112^ schizophrenia,^80^ or mixed conditions.^186, 188^ No patient receiving aripiprazole or risperidone (N = 60) had an abnormal ECG or pathological elongation in QTc values.^188^ Anomalies on ECG were found for 2 of 12 and 1 of 13 patients on clozapine and olanzapine, respectively—none of which led to drug discontinuation.^80^ None of the patients taking quetiapine or risperidone (N =22) had an abnormal ECG in one RCT.^112^ Finally, one patient taking clozapine and olanzapine compared with none taking risperidone had an ECG alteration, without serious effects.^186^

Agranulocytosis and related effects. Two RCTs^78, 80^ (N = 64) comparing clozapine with olanzapine for patients with schizophrenia reported on neutropenia for two patients taking each drug. One patient on clozapine developed neutropenia in a prospective observational study comparing clozapine, olanzapine, and risperidone for adverse effects (N = 51).^186^

##### Major AEs During Long-Term (≥ 6 Months) Treatment

Major AEs and major AEs limiting treatment. A 6-month RCT^67^ (N = 50) comparing olanzapine with quetiapine in adolescents with a first psychotic episode reported that no patient experienced a major AE.

Development of diabetes mellitus. Three long-term observational studies examined development of diabetes in children taking various SGAs. Bobo et al.^193^ conducted a retrospective cohort study of the Tennessee Medicaid program to investigate newly diagnosed type 2 diabetes in recent initiators of antipsychotics for conditions of which these drugs are not considered primary treatment (i.e., excluded patients with schizophrenia, ASD, tic disorders, and all patients taking clozapine). The absolute and relative risks for diabetes based on baseline antipsychotic exposure status are listed below; the difference between the hazard ratios (HR) for risperidone and aripiprazole was statistically significant (p < 0.0001).

- Risperidone (15,608 person-years): 16.7 cases per 10,000 person-years; HR 2.20, 95% CI 1.14 to 4.26
- Olanzapine (7,778 person-years): 20.6 cases per 10,000 person-years; HR 2.17, 95% CI 1.04 to 4.53
- Quetiapine (6,554 person-years): 30.5 cases per 10,000 person-years; HR 2.76, 95% CI 1.37 to 5.56
- Aripiprazole (2,470 person-years): 72.9 cases per 10,000 person-years; HR 7.72, 95% CI 3.70 to 16.12
- Ziprasidone (832 person-years): 48.1 cases per 10,000 person-years; HR 4.15, 95% CI 1.35 to 12.73

Censoring followup to whether switching of drugs occurred did not change the above findings (data not presented). Moreover, across all antipsychotics the risk remained elevated for up to one-year following discontinuation of the drug. Another study reporting on 5-year followup of 47 patients with early-onset psychosis taking various SGAs (risperidone, olanzapine, quetiapine, aripiprazole, clozapine), found that one patient taking clozapine was diagnosed with diabetes after 2 years of treatment.^102^ A small study (N = 37) comparing risperidone and quetiapine found that no patient developed type 2 diabetes after a 12-month period.^180^

Seizures. One long-term prospective cohort study (N = 60) reported that no patient having a first episode of psychosis experienced seizures at 6 months in groups continuously receiving risperidone, quetiapine, or olanzapine.^101^

Tardive dyskinesia. A 12-month (N = 34) comparison between olanzapine and risperidone, in patients with schizophrenia responding to an 8-week trial, there were no incident cases of tardive dyskinesia.^81^

##### General AEs During Short- and Long-Term Treatment

Findings for any AE limiting treatment are contained in Table 32; only comparisons having more than two studies are included. Tables 33 and 34 present the findings for other general AEs having at least low SOE during short- and long-term treatment, respectively; the table footnotes provide rationale for the SOE assessments. All findings between clozapine and risperidone, and most between clozapine and olanzapine, were considered to have insufficient SOE mainly due to impression (all samples < 100 and wide 95% CIs), but also because of moderate ROB (weight) and inconsistency (BMI) for the risperidone comparisons. Likewise, the SOE was insufficient for findings in comparisons between aripiprazole and risperidone; apart from ROB, imprecision (akathisia, somnolence) and inconsistency (weight) were too great.

Table 32 Findings for adverse effects (AEs) limiting treatment in comparisons between different SGAs

Comparison (G1 vs. G2) | Outcome | N Studies, N Patients | G1 Events | G1 N | G2 Events | G2 N | Relative Effects^a^, Studies
Aripiprazole vs. Risperidone | AE limiting treatment | 2, 272 | 0 | 34 | 0 | 35 | Not estimable^159^
Aripiprazole vs. Risperidone | AE limiting treatment | | 4 | 66 | 6 | 137 | RR, 1.38; 95% CI, 0.40 to 4.74^179^
Aripiprazole vs. Ziprasidone | AE limiting treatment | 2, 115 | 2 | 20 | 6 | 14 | RR, 0.23; 95% CI, 0.05 to 0.99^192^
Aripiprazole vs. Ziprasidone | AE limiting treatment | | 4 | 66 | 0 | 15 | RR, 2.15; 95% CI, 0.12 to 37.92^183^
Clozapine vs. Olanzapine | AE limiting treatment | 2, 65 | 0 | 2 | 9 | 24 | RR, 0.44; 95% CI, 0.03 to 5.78^191^
Clozapine vs. Olanzapine | AE limiting treatment | | 2 | 18 | 1 | 21 | RR, 2.33; 95% CI, 0.23 to 23.66^78^
Clozapine vs. Olanzapine
Clozapine vs. Olanzapine | AE limiting treatment (12+ mo) | 2, 65 | 1 | 12 | 0 | 13 | RR, 3.23; 95% CI, 0.14 to 72.46^80^
Clozapine vs. Olanzapine | AE limiting treatment (12+ mo) | | 4 | 28 | 4 | 12 | RR, 0.43; 95% CI, 0.13 to 1.44^102^
Olanzapine vs. Quetiapine | AE limiting treatment | 2, 150 | 9 | 24 | 1 | 2 | RR, 0.75; 95% CI, 0.17 to 3.29^191^
Olanzapine vs. Quetiapine | AE limiting treatment | | 1 | 58 | 0 | 66 | RR, 3.41; 95% CI, 0.14 to 82.04^183^
Olanzapine vs. Quetiapine
Olanzapine vs. Quetiapine | AE limiting treatment (6 to <12 mo) | 2, 84 | 0 | 26 | 0 | 24 | Not estimable^67^
Olanzapine vs. Quetiapine | AE limiting treatment (6 to <12 mo) | | 2 | 18 | 1 | 16 | RR, 1.78; 95% CI, 0.18 to 17.80^101^
Olanzapine vs. Risperidone | AE limiting treatment | 6, 436 | 16 | 164 | 30 | 272 | RR, 0.87; 95% CrI, 0.21 to 2.18^79, 81, 82, 99, 183, 191^
Olanzapine vs. Risperidone
Olanzapine vs. Risperidone | AE limiting treatment (12+ mo) | 3, 148 | 12 | 43 | 23 | 105 | RR, 1.23; 95% CrI, 0.36 to 4.09^81, 101, 102^
Olanzapine vs. Ziprasidone | AE limiting treatment | 6, 436 | 16 | 164 | 30 | 272 | RR, 0.87; 95% CrI, 0.21 to 2.18^79, 81, 82, 99, 183, 191^
Olanzapine vs. Ziprasidone
Olanzapine vs. Ziprasidone | AE limiting treatment (12+ mo) | 3, 148 | 12 | 43 | 23 | 105 | RR, 1.23; 95% CrI, 0.36 to 4.09^81, 101, 102^
Quetiapine vs. Risperidone | AE limiting treatment | 2, 250 | 1 | 2 | 13 | 45 | RR, 1.73; 95% CI, 0.40 to 7.45^191^
Quetiapine vs. Risperidone | AE limiting treatment | | 0 | 66 | 6 | 137 | RR, 0.16; 95% CI, 0.01 to 2.77^183^

AE = adverse effect; CI = confidence interval; CrI = credible interval; G = group; N = number; mo = months; RR = risk ratio

a RRs above 1.0 favor group 2. We did not combine data from 1 or 2 studies so these results are always presented separately.

Table 33 Summary of findings for general adverse effects: Short-term findings of comparisons between different SGAs

Comparison (G1 vs. G2) | Outcome | N Studies, N Patients | G1 Events | G1 N | G2 Events | G2 N | Relative Effects^a^, Studies | Strength of Evidence; Conclusions
Clozapine vs. Olanzapine | Weight (kg) | 5 (136) | - | 62 | - | 74 | MD, −1.56; 95% CrI, −5.12 to 1.57^78, 80, 97, 98, 186^ | Low; may make little or no difference ^b^
Olanzapine vs. Quetiapine | Weight (kg) | 3 (232) | - | 116 | - | 116 | MD, 4.00; 95% CrI, −1.67 to 10.79^181, 183, 187^ | Low; may make little or no difference ^c^
Olanzapine vs. Quetiapine | BMI (kg·m^−2^) | 3 (232) | - | 116 | - | 116 | MD, 1.36; 95% CrI, −0.29 to 3.40^181, 183, 187^ | Low; may make little or no difference ^c^
Olanzapine vs. Quetiapine | ≥ 7% increase in weight | 3 (192) | 72 | 99 | 47 | 93 | RR: 1.41; 95% CI, 0.65 to 2.83^74, 177, 179^ | Low; may make little or no difference ^c^
Olanzapine vs. Risperidone | Weight (kg) | 13 (936) | - | 331 | - | 605 | MD, 2.18; 95% CrI, 1.13 to 3.25^69, 79, 81, 82, 85, 97, 99, 113, 181, 183, 186, 187, 189^ | Moderate; Risperidone probably slightly better^d^
Olanzapine vs. Risperidone | BMI (kg·m^−2^) | 9 (737) | - | 244 | - | 493 | MD, 0.94; 95% CrI, 0.64 to 1.30^69, 81, 82, 99, 181, 183, 186, 187, 197^ | Moderate; Risperidone probably slightly better^d^
Olanzapine vs. Risperidone | ≥ 7% increase in weight | 6 (504) | 107 | 150 | 188 | 354 | RR, 1.36; 95% CrI, 0.93 to 2.04^75, 85, 99, 181, 183, 186^ | Low; may make little or no difference ^c^
Olanzapine vs. Risperidone | Sedation | 7 (321) | 35 | 133 | 36 | 188 | RR, 1.19; 95% CrI, 0.73 to 2.35^75, 81, 82, 99, 113, 191, 195^ | Low; may make little or no difference ^c^
Quetiapine vs. Risperidone | Weight (kg) | 3 (463) | - | 116 | - | 347 | MD, 0.08; 95% CrI, −3.77 to 3.14^181, 183, 187^ | Low; may make little or no difference ^f^
Quetiapine vs. Risperidone | BMI (kg·m^−2^) | 3 (463) | - | 116 | - | 347 | MD, 0.04; 95% CrI, −1.34 to 1.20^181, 183, 187^ | Moderate; probably makes little or no difference ^d^
Quetiapine vs. Risperidone | ≥ 7% increase in weight | 4 (417) | 55 | 104 | 176 | 313 | RR: 0.91; 95% CI, 0.56 to 1.44^75, 84, 181, 183^ | Moderate; probably makes little or no difference ^d^
Quetiapine vs. Risperidone | Hyperprolactinemia | 4 (118) | 4 | 31 | 45 | 87 | RR, 0.20; 95% CrI, 0.06 to 0.73^84, 112, 190, 191^ | Low; Quetiapine may decrease risk^e^

BMI = body mass index; CrI = credible interval; kg = kilogram; m = meters; MD = mean difference; N = number; RR = risk ratio

a Positive MDs favor group 2; RR above 1.0 favor group 2

b Downgraded for ROB and imprecision, because CrI includes possibility for clinically relevant benefit for group 1.

c Downgraded for ROB and imprecision, because CrI includes possibility for clinically relevant benefit for group 2.

d Downgraded for ROB.

e Downgraded for ROB and imprecision, based on small sample size.

f Downgraded for ROB and inconsistency.

Table 34 Summary of findings for general adverse effects: Long-term findings of comparisons between different SGAs

Comparison | Outcome, Duration | N Studies, N Patients | G1 Events | G1 N | G2 Events | G2 N | Relative Effects^a^, Studies | Strength of Evidence for Direction of Effect
Olanzapine vs. Quetiapine | Weight (kg), 6 to <12mo | 3 (185) | - | 90 | - | 95 | MD, 7.91; 95% CrI, 3.65 to 12.29^67, 181, 187^ | Moderate; Quetiapine probably better^b^
Olanzapine vs. Quetiapine | BMI (kg·m^−2^), 6 to <12mo | 4 (203) | - | 99 | - | 104 | MD, 2.68; 95% CrI, 0.96 to 4.27^67, 101, 181, 187^ | Moderate; Quetiapine probably better^b^
Olanzapine vs. Risperidone | Weight (kg), 6 to <12mo | 4 (295) | - | 85 | - | 210 | MD, 4.40; 95% CrI, −0.54 to 9.86^81, 181, 186, 187^ | Low; may make little or no difference ^c^
Olanzapine vs. Risperidone | BMI (kg·m^−2^), 6 to <12mo | 5 (328) | - | 94 | - | 234 | MD, 1.66; 95% CrI, 0.19 to 3.42^81, 101, 181, 186, 187^ | Moderate; Risperidone probably slightly better^b^
Olanzapine vs. Risperidone | ≥ 7% increase in weight, 6 to <12 mo | 3 (264) | 28 | 64 | 64 | 200 | RR: 1.44; 95% CI, 0.55 to 5.50}^102, 181, 186^ | Low; may make little or no difference ^c^
Quetiapine vs. Risperidone | Weight (kg), 6 to <12mo | 3 (295) | - | 93 | - | 202 | MD, −1.48; 95% CrI, −4.16 to 1.18^180, 181, 187^ | Low; may make little or no difference ^d^
Quetiapine vs. Risperidone | BMI (kg·m^−2^), 6 to <12mo | 4 (328) | - | 102 | - | 226 | MD, −0.32; 95% CrI, −1.56 to 1.12^101, 181, 187^ | Low; may make little or no difference ^d^

BMI = body mass index; CI = confidence interval; CrI = credible interval; kg = kilogram; m = meter; MD = mean difference; mo = months; N = number; RR = risk ratio

a Positive MDs and RRs above 1.0 favor group 2.

b Downgraded for ROB.

c Downgraded for ROB and imprecision, because CrI includes possibility for clinically relevant benefit for group 2.

d Downgraded for ROB and imprecision, because of small sample sizes.

### SGAs Versus SGAs: Dose Comparisons

Findings for major and general AEs in comparisons between two or more doses of the same SGAs are presented below. Only one study^108^ reported on long-term treatment, for a comparison between low- and high-dose aripiprazole for bipolar disorder.

#### Key Points: Major AEs

- The effects between different doses of SGAs in terms of major AEs during short-term treatment are mostly unknown (insufficient SOE).
- There may be no difference between 5 mg/day and 10 mg/day asenapine for risk of developing diabetes over 8 weeks of treatment (low SOE); both groups (n = 98, n = 102) had 7 percent incidence of possible new-onset diabetes (compared with 4 percent in placebo group).^92^

#### Key Points: General AEs

- Aripiprazole (three RCTs^73, 117, 131^, and a prospective cohort^185^): Different doses of aripiprazole are probably of little or no difference for short-term weight gain. There may be little or no difference between doses for any EPS symptoms, BMI, the proportion gaining 7 percent or more weight, and somnolence (all short-term); for these outcomes the 95% CIs included values favoring the low dose. There may be little or no difference for hypertriglyceridemia or increased total cholesterol.
- Asenapine (two RCTs^92,108^): There is probably little or no difference in the short-term between low and high doses of asenapine for weight gain, the proportion of patients gaining 7 percent or more weight, risk of somnolence, or risk for hyperprolactinemia.
- Quetiapine (two RCTs^72,119^): Low and high doses of quetiapine are probably of little or no difference for risk of gaining greater than 7 percent weight, somnolence, or sedation over the short-term.
- Risperidone (four RCTs^74, 88, 118, 128^): Risks for somnolence and EPS symptoms may be of little or no difference between low- and high-dose risperidone during short-term treatment; SOE was affected by ROB and inconsistency (somnolence) and imprecision (EPS symptoms).

#### Detailed Analysis

##### Major AEs During Short-Term (< 6 Months) Treatment

###### Aripiprazole

Three RCTs (schizophrenia,^73^ bipolar disorder,^117^ and ASD^131^) and a prospective cohort study^185^ (mixed conditions) compared different doses of aripiprazole. One RCT^117^ reported short- and long-term (30 week) results. The RCTs (N = 512) compared low-doses (5 and 10 mg/day,^131^ or 10 mg/day^73, 117^) with high-doses (15 mg/day,^131^ or 30 mg/day^73, 117^); our synthesis below focuses on the differences between these doses. The cohort study^185^ (N = 21) investigated three high doses (20, 25, and 30 mg/day) for 3–4 weeks of treatment, and reported that no major AEs, deaths, or clinically relevant ECG changes occurred.

Major AEs and major AEs limiting treatment. Ten of 257 patients receiving a 10 mg/day dose of aripiprazole had a major AE, as did 6 of 255 assigned to the high-dose groups.^73, 117, 131^ At 30-week followup, one (low dose, N = 75) and five (high dose, N = 71) patients had a major AE.^117^

Mortality. No patient receiving low- or high-dose aripiprazole died during short-term ^73, 117, 131^ or longer term treatment.^117^

Seizures. No patient on any dose in the study of Marcus et al.^131^ experienced a seizure.

Tardive dyskinesia. Thirty-week treatment with aripiprazole did not result in any case of tardive dyskinesia.^117^

Cardiac arrhythmias. One RCT reported that four in the low dose (N = 98) and two in the high-dose (N = 99) groups had an abnormal QTcB value.^117^

###### Asenapine

Low-, medium-, and high-dose comparisons of asenapine were studied in two short-term RCTs for patients with schizophrenia (5 vs. 10 mg/day, 8 weeks, N = 204)^92^ and bipolar disorder (5 vs. 10 vs. 20 mg/day, 3 weeks, N = 302).^108^

Major AEs and major AEs limiting treatment. Three patients in each of the low- and medium dose groups experienced a major AE in the longer study of schizophrenia,^92^ and no patient in any group had a major AE in other RCT.^108^

Mortality. No patient in either study died.^92, 108^

Development of diabetes. Potential new-onset diabetes was identified in 7 patients (7%) in each of the low- and medium-dose asenapine groups in the 8-week RCT (compared with 4% of placebo-treated patients).^92^ This study also found that 3 patients (1 receiving low dose and 2 receiving medium dose) developed metabolic syndrome.

Cardiac arrhythmias. Prolongation of the QTc interval was reported for one patient in each low-dose group of both asenapine studies,^92, 108^ one patient in the medium-dose group in one study,^91, 107^ and no patient receiving high-dose asenapine in the RCT including this dose.^108^

###### Lurasidone

Two RCTs studied different doses of lurasidone in patients with autism (20mg/day and 60mg/day, N = 100)^127^ and schizophrenia, bipolar, autism, ADHD, or tourette’s syndrome (20 vs. 40 vs. 80 vs. 120 vs. 160mg/day, N = 105).^179^

Major AEs and major AEs limiting treatment. Patients who discontinued due to major AEs were two in the 20 mg/day group, two in the 60 mg/day group^127^, two in the 40 mg/day group, five in the 80mg/day group and one in the 120 mg/day group. ^179^

###### Paliperidone

Two RCTs^89, 90^ studied different doses of paliperidone in patients with schizophrenia and related disorders. In a dose escalation study of 6, 9, or 12 mg/day doses (N = 25), no patient had a serious AE (including death), but 1, 3, and 3 patients, respectively, had a prolonged value for the QTcB interval.^89^ The other RCT^90^ (N = 149) evaluated low (1.5 mg/day), medium (3 or 6 mg/day depending on weight), and high (6 or 12 mg/day) doses of paliperidone for 6 weeks; major AEs were rare (2, 1, and 1, respectively) and no patient died, developed tardive dyskinesia, experienced seizures, or had a prolonged QTcLD.

###### Quetiapine

Different doses of quetiapine were investigated in two RCTs—one compared 400 with 800 mg/day for 6 weeks in 147 patients with schizophrenia,^72^ and the other compared 400 and 600 mg/day for 3 weeks in 193 patients with bipolar disorder.^119^

Major AEs and major AEs limiting treatment. Major AEs were experienced in four and five patients taking low and high doses in one study,^72^ and five and four patients allocated to low and medium doses of quetiapine in another.^119^

Development of diabetes. Three patients taking low-dose and two patients taking medium dose quetiapine reported diabetes-related AEs (i.e., thirst, increased insulin and glycosolated hemoglobin).^119^

Cardiac arrhythmias. Multiple ECG variables were reported for patients taking low, medium, and high doses of quetiapine;^72, 119^ no abnormal values were found for any patient.

Agranulocytosis and related effects. For both quetiapine studies,^72, 119^ a shift to low neutrophil counts was found for five patients in the low-dose groups (N = 168), four patients taking a medium dose (N = 98), and one patient taking high dose (N = 74) of quetiapine.

###### Risperidone

Four short-term RCTs compared different doses of risperidone in schizophrenia,^74, 88^ bipolar disorder,^118^ and ASD.^128^ Two studies included a low dose (0.125–0.6 mg/day; N = 162),^74, 128^ three a medium dose (1.25–2.5 mg/day; N = 136),^88, 118, 128^ one a high dose (1.5–6 mg/day; N = 125),^74^ and two a higher dose (4–6 mg/day; N = 112).^88, 118^ Study durations were 3,^118^ 6,^88, 128^ and 8 weeks.^74^

Four to six patients experienced a major AE in each of the four dose categories. No patient died in any group in the four RCTs. One study^74^ reported that neither low nor high dose groups had a patient developing diabetes. Two studies reported that no patient developed tardive dyskinesia in up to a 4–6 mg/day dose,^88, 128^ and none of the patients allocated to low or high-dose risperidone had a QTc prolongation.^74^

###### Ziprasidone

One RCT^65^ compared the tolerability of 80 and 160 mg/day of ziprasidone in 63 patients with schizophrenia or bipolar disorder. Five of 23 taking low-dose and 8 of 40 taking high-dose ziprasidone experienced major AEs. No patient had a prolonged QTcF interval > 450 ms.

##### General AEs During Short- and Long-Term Treatment

Tables 35 and 36 include the findings, respectively, for any AE limiting treatment and for other outcomes where there was at least low SOE for an outcome of general AEs in studies comparing different doses of SGAs. The doses considered are identified for each drug.

Table 35 Findings for any AE limiting treatment in short-term comparisons between different doses of SGAs

Comparison | High Dose Events | High Dose N | Low Dose Events | Low Dose N | Relative Effects^a^, Studies
Aripiprazole High (15/30mg/day) vs. Low (10mg/day) | 15 | 255 | 19 | 257 | RR, 0.80; 95% CrI, 0.22 to 3.04^73, 117, 131^
Asenapine High (10mg/day) vs. Low (5mg/day) | 8 | 106 | 6 | 98 | RR, 1.23; 95%CI, 0.44 to 3.43^92^
Asenapine High (10mg/day) vs. Low (5mg/day) | 3 | 99 | 7 | 104 | RR, 0.45; 95% CI, 0.12 to 1.69^108^
Lurasidone High (60/160mg/day) vs. Low (20mg/day) | 0 | 16 | 0 | 20 | Not estimable^179^
Lurasidone High (60/160mg/day) vs. Low (20mg/day) | 2 | 49 | 2 | 51 | RR, 1.04; 95% CI, 0.14 to 7.71^127^
Paliperidone High (6/12mg/day) vs. Low (3/6mg/day) | 0 | 8 | 0 | 8 | Not estimable^89^
Paliperidone High (6/12mg/day) vs. Low (3/6mg/day) | 1 | 48 | 1 | 48 | RR, 1.00; 95% CI, 0.06 to 15.53^90^
Quetiapine High (600/800 mg/day) vs. Low (400 mg/day) | 7 | 74 | 5 | 73 | RR, 1.38; 95% CI, 0.46 to 4.15^72^
Quetiapine High (600/800 mg/day) vs. Low (400 mg/day) | 7 | 98 | 15 | 95 | RR, 0.45; 95% CI, 0.19 to 1.06^119^
Risperidone High (3–6mg/day) vs. Low (0.5–3mg/day) | 4 | 51 | 3 | 55 | RR, 1.44; 95% CI, 0.34 to 6.12^88^
Risperidone High (3–6mg/day) vs. Low (0.5–3mg/day) | 10 | 61 | 3 | 50 | RR, 2.73; 95% CI, 0.79 to 9.39^118^

CI = confidence interval; CrI = credible interval; N = number; RR = risk ratio.

a RR above 1.0 favor low dose groups. We did not combine data from 1 or 2 studies so these results are always presented separately.

Table 36 Summary of findings for general adverse effects: Short-term findings from comparisons between different doses of SGAs

Comparison | Outcome | High dose events | High dose N | Low dose events | Low dose N | Relative Effects^a^, Studies | Strength of Evidence; Conclusions
Aripiprazole High (15/30mg/day) vs. Low (10mg/day) | Any EPS | 39 | 99 | 23 | 98 | RR, 1.68; 95% CI, 1.09 to 2.59^117^ | Low; may make little or no difference ^b^
Aripiprazole High (15/30mg/day) vs. Low (10mg/day) | | 12 | 54 | 13 | 59 | RR, 1.01; 95% CI, 0.50 to 2.02^131^
Aripiprazole High (15/30mg/day) vs. Low (10mg/day)
Aripiprazole High (15/30mg/day) vs. Low (10mg/day) | Weight (kg) | - | 229 | - | 234 | MD, 0.22; 95% CrI, −0.64 to 1.09^73, 117, 131^ | Moderate; probably makes little or no difference ^c^
Aripiprazole High (15/30mg/day) vs. Low (10mg/day)
Aripiprazole High (15/30mg/day) vs. Low (10mg/day) | BMI (kg·m^−2^) | - | 223 | - | 233 | MD, 0.14; 95% CrI, −0.47 to 5.86^73, 117, 131^ | Low; may make little or no difference ^b^
Aripiprazole High (15/30mg/day) vs. Low (10mg/day)
Aripiprazole High (15/30mg/day) vs. Low (10mg/day) | ≥ 7% weight increase | 37 | 250 | 24 | 256 | RR, 1.62; 95% CrI, 0.47 to 5.86^73, 117, 131^ | Low; may make little or no difference ^b^
Aripiprazole High (15/30mg/day) vs. Low (10mg/day)
Aripiprazole High (15/30mg/day) vs. Low (10mg/day) | High cholesterol | 28 | 65 | 27 | 64 | RR, 1.02; 95% CI, 0.68 to 1.52^116^ | Low; may make little or no difference ^d^
Aripiprazole High (15/30mg/day) vs. Low (10mg/day) | | 0 | 54 | 0 | 59 | Not estimable^131^
Aripiprazole High (15/30mg/day) vs. Low (10mg/day)
Aripiprazole High (15/30mg/day) vs. Low (10mg/day) | High triglycerides | 22 | 65 | 22 | 65 | RR, 1.00; 95% CI, 0.62 to 1.62^117^ | Low; may make little or no difference ^d^
Aripiprazole High (15/30mg/day) vs. Low (10mg/day) | | 2 | 54 | 6 | 59 | RR: 0.36; 95% CI, 0.08 to 1.73^129^
Aripiprazole High (15/30mg/day) vs. Low (10mg/day)
Aripiprazole High (15/30mg/day) vs. Low (10mg/day) | Somnolence | 62 | 255 | 47 | 257 | RR, 1.31; 95% CrI, 0.46 to 3.80^73, 117, 131^ | Low; may make little or no difference ^b^
Asenapine High (10mg/day) vs. Low (5mg/day) | BMI (kg·m^−2^) | -- | - | - | - | MD, 0.03; 95% CI, −0.04 to 0.10^92^ | Low; may make little or no difference^e^
Asenapine High (10mg/day) vs. Low (5mg/day)
Asenapine High (10mg/day) vs. Low (5mg/day) | ≥ 7% weight increase | 10 | 99 | 9 | 95 | RR, 1.07; 95% CI, 0.45 to 2.51^92^ | Moderate; probably makes little or no difference ^f^
Asenapine High (10mg/day) vs. Low (5mg/day) | | 8 | 90 | 11 | 92 | RR, 0.74; 95% CI, 0.31 to 1.76^108^ | Moderate; probably makes little or no difference ^f^
Asenapine High (10mg/day) vs. Low (5mg/day)
Asenapine High (10mg/day) vs. Low (5mg/day) | Somnolence | 31 | 106 | 24 | 98 | RR, 1.19; 95% CI, 0.76 to 1.89^92^ | Moderate; probably makes little or no difference ^f^
Asenapine High (10mg/day) vs. Low (5mg/day) | | 52 | 99 | 49 | 104 | RR, 1.11; 95% CI, 0.85 to 1.47^108^ | Moderate; probably makes little or no difference ^f^
Asenapine High (10mg/day) vs. Low (5mg/day)
Asenapine High (10mg/day) vs. Low (5mg/day) | Hyperprolactinemia | 20 | 106 | 23 | 98 | RR, 1.24; 95% CI, 0.73 to 2.12^92^ | Low; may make little or no difference^e^
Quetiapine High (600/800 mg/day) vs. Low (400 mg/day) | ≥ 7% weight increase | 14 | 74 | 17 | 73 | RR, 0.81; 95% CI, 0.43 to 1.52^72^ | Moderate; probably makes little or no difference^c^
Quetiapine High (600/800 mg/day) vs. Low (400 mg/day) | ≥ 7% weight increase | 10 | 98 | 14 | 95 | RR, 0.69; 95% CI, 0.32 to 1.48^119^ | Moderate; probably makes little or no difference^c^
Quetiapine High (600/800 mg/day) vs. Low (400 mg/day)
Quetiapine High (600/800 mg/day) vs. Low (400 mg/day) | Somnolence | 22 | 74 | 20 | 73 | RR, 1.09; 95% CI, 0.65 to 1.81^72^ | Moderate; probably makes little or no difference ^c^
Quetiapine High (600/800 mg/day) vs. Low (400 mg/day) | | 31 | 98 | 27 | 95 | RR, 1.11; 95% CI, 0.72 to 1.71^119^ | Moderate; probably makes little or no difference ^c^
Quetiapine High (600/800 mg/day) vs. Low (400 mg/day)
Quetiapine High (600/800 mg/day) vs. Low (400 mg/day) | Sedation | 4 | 74 | 4 | 73 | RR, 0.99; 95% CI, 0.26 to 3.80^72^ | Moderate; probably makes little or no difference ^c^
Quetiapine High (600/800 mg/day) vs. Low (400 mg/day) | | 25 | 98 | 22 | 95 | RR, 1.10; 95% CI, 0.67 to 1.81^119^ | Moderate; probably makes little or no difference ^c^
Risperidone High (3–6mg/day) vs. Low (0.5–3mg/day) | Any EPS | 20 | 51 | 18 | 55 | RR, 1.20; 95% CI, 0.72 to 2.00^88^ | Low; may make little or no difference ^b^
Risperidone High (3–6mg/day) vs. Low (0.5–3mg/day) | | 15 | 61 | 4 | 50 | RR, 3.07; 95% CI, 1.09 to 8.68^118^ | Low; may make little or no difference ^b^
Risperidone High (3–6mg/day) vs. Low (0.5–3mg/day)
Risperidone High (3–6mg/day) vs. Low (0.5–3mg/day) | Somnolence | 6 | 51 | 13 | 55 | RR, 0.50; 95% CI, 0.20 to 1.21^88^ | Low; may make little or no difference ^g^
Risperidone High (3–6mg/day) vs. Low (0.5–3mg/day) | | 34 | 61 | 21 | 50 | RR, 1.33; 95% CI, 0.89 to 1.97^118^ | Low; may make little or no difference ^g^

AE = adverse effect; BMI=body mass index; CI = confidence interval; CrI = credible interval; EPS = extrapyramidal symptoms; kg = kilogram; m = meter; mg = milligrams; MD = mean difference; N = number; RR = risk ratio

a Positive MDs and RRs above 1.0 favor the low dose group. We did not combine data from 1 or 2 studies so these results are always presented separately.

b Downgraded for ROB and imprecision, because CIs include possibility for clinically relevant benefit for the low dose group.

c Downgraded for ROB.

d Downgraded for ROB and imprecision due to small sample sizes.

e Downgraded for unknown consistency and imprecision from small smaples.

f Downgraded for imprecision, because CIs include possibility for clinically relevant benefit for the low dose group

g Downgraded for ROB and inconsistency between studies.

One RCT^117^ provided data for long-term placebo-controlled followup of a comparison of low (10 mg/day) and high (30 mg/day) doses of aripiprazole in patients with bipolar disorder responding to acute treatment. No significant differences were noted between doses for many AEs; Appendix G contains the findings for this study and the results from the other studies where SOE was insufficient, mainly due to risk of bias and imprecision from small samples in cases of rare events.

### FGAs Versus Placebo

Findings for major and general AEs in comparisons between FGAs and placebo are presented below.

#### Key Points

- No findings for major or general AEs in comparisons between FGAs and placebo offered greater than insufficient SOE.

#### Detailed Analysis

##### Major AEs During Short-Term (< 6 Months) Treatment

Major AEs and major AEs limiting treatment. One RCT^168^ (N = 44) reported than two patients with tic disorders receiving haloperidol and none receiving placebo experienced major AEs limiting treatment.

Seizures. Two patients with ADHD experienced seizures while receiving thoridazine and placebo (3 weeks each) in one cross-over RCT (N = 60).^150^

##### Major AEs During Long-Term (≥ 6 Months) Treatment

Tardive dyskinesia. No patient developed tardive dyskinesia in a small (N = 10) placebo-controlled maintenance RCT of pimozide versus placebo in tic disorders.^171^

##### General AEs During Short- or Long-Term (< 6 Months) Treatment

No findings for our key general AEs in comparisons between FGAs and placebo offered greater than insufficient SOE. Four small studies reported on general AEs to a varying extent with most outcomes having data for one study. A meta-analysis (N = 153) was conducted for the outcome of AEs limiting treatment in three comparisons between FGAs and placebo; no significant difference was found (RR, 2.43; 95% CrI, 0.47 to 23.08).^137, 168^

### SGAs Versus Placebo

Findings for major and general AEs in comparisons between SGAs and placebo are presented below.

#### Key Points: Major AEs

- There is probably little or no difference in the short-term across all SGAs compared with placebo for mortality or for having a pathologically prolonged QT interval.
- Compared with no antipsychotic treatment, SGAs may increase the risk for developing diabetes (low SOE). A large retrospective cohort study compared incidence of type 2 diabetes in patients newly initiated on antipsychotics compared with matched patients not taking antipsychotics for at least 1 year; taking SGAs was associated with an increased risk (HR 2.89, 95% CI 1.64 to 5.10; 25.3 vs. 7.8 cases per 10,000 person-years followup).^193^
- Other outcomes were assessed as having insufficient SOE due to rare events occurring in samples too small to offer adequate power.

#### Key Points: General AEs

- All SGAs versus placebo. SGAs are likely better than placebo for seven outcomes: any EPS symptoms, changes to body composition (weight, BMI, and ≥7% weight gain), increased triglycerides, sedation, and somnolence. The proportion of patients having high total cholesterol may be higher from taking SGAs. There may be little or no difference between SGAs and placebo for risk of akathisia. In the longer term, few studies provided insufficient SOE.
- Individual SGAs.
  ○ Aripiprazole is likely slightly worse than placebo/no treatment for gains in weight and BMI, and may increase risk for any EPS, ≥7 percent weight gain, and somnolence.
  ○ Compared with placebo, olanzapine probably increases weight gain and BMI, and appears to increase risk for ≥7 percent weight gain and hyperprolactinemia.
  ○ Quetiapine likely increases slightly weight gain, and may make little or no difference in risk for sedation and somnolence.
  ○ Risperidone probably increases slightly weight gain and BMI, and likely increases risk for somnolence. It may increase risk for any EPS symptoms. In long-term studies, there appears to be little or no difference in changes in weight and BMI.
  ○ Ziprasidone probably makes little or no difference for weight gain, and may make little or no difference for somnolence.

#### Detailed Analysis

##### Major AEs During Short-Term (< 6 Months) Treatment

Table 37 includes all the findings on major AEs from studies comparing SGAs with placebo. Assessment of the SOE was not performed for the outcomes of any major AE, or for major AEs limiting treatment. Our SOE assessments were based on risk differences (absolute risks) for major AEs having very low event rates.

Table 37 Summary of findings for major adverse effects: Short-term findings for SGA versus placebo

Comparison | Outcome | N Studies, N Patients, Studies | SGA Events | SGA N | Placebo Events | Placebo N | Strength of Evidence; Conclusions
All SGAs vs Placebo/No treatment | Any MAE | 26, 4282^71–73, 88, 90, 92, 106, 108, 109, 115–120, 123, 131, 132, 135, 139, 141, 147, 151, 154, 161, 167^ | 103 | 2739 | 45 | 1543 | NA
All SGAs vs Placebo/No treatment
All SGAs vs Placebo/No treatment | MAE limiting treatment | 7, 950^71, 106, 108, 114, 128, 139, 167^ | 14 | 629 | 5 | 321 | NA
All SGAs vs Placebo/No treatment
All SGAs vs Placebo/No treatment | Mortality | 13, 2447^73, 88, 90, 106, 108, 116–118, 120, 123, 128, 131, 135^ | 0 | 1635 | 0 | 812 | Moderate; probably makes little or no difference ^a^
All SGAs vs Placebo/No treatment
All SGAs vs Placebo/No treatment | Diabetes mellitus | 3, 703^92, 109, 119^ | 21 | 436 | 4 | 267 | Insufficient
All SGAs vs Placebo/No treatment | | | | | | | Insufficient
All SGAs vs Placebo/No treatment | NMS | 2, 252^90, 125^ | 0 | 175 | 0 | 77 | Insufficient
All SGAs vs Placebo/No treatment | | | | | | | Insufficient
All SGAs vs Placebo/No treatment | Seizures | 2, 416^90, 131^ | 0 | 314 | 1 | 102 | Insufficient
All SGAs vs Placebo/No treatment | | | | | | | Insufficient
All SGAs vs Placebo/No treatment | TD | 5, 570^88, 118, 125, 139, 158^ | 0 | 336 | 2 | 234 | Insufficient
All SGAs vs Placebo/No treatment
All SGAs vs Placebo/No treatment | Cardiac Arrhythmia | 14, 2425^71, 72, 90, 92, 108, 109, 114, 117, 119, 135, 139, 151, 158, 172^ | 19 | 1490 | 9 | 935 | Moderate; probably makes little or no difference ^a^
All SGAs vs Placebo/No treatment
All SGAs vs Placebo/No treatment | Agranulocytosis and related effects | 5, 885^72, 109, 119, 120, 132^ | 14 | 514 | 7 | 371 | Insufficient
Aripiprazole vs. Placebo | MAE | 7, 1081^73, 106, 117, 123, 131, 135, 139^ | 17 | 701 | 8 | 380 | NA
Aripiprazole vs. Placebo
Aripiprazole vs. Placebo | MAE limiting treatment | 1, 59^106^ | 2 | 30 | 1 | 29 | NA
Aripiprazole vs. Placebo
Aripiprazole vs. Placebo | Mortality | 6, 1051^73, 106, 117, 123, 131, 135^ | 0 | 680 | 0 | 371 | Low; may make little or no difference ^b^
Aripiprazole vs. Placebo
Aripiprazole vs. Placebo | Seizures | 1, 216^131^ | 0 | 165 | 1 | 51 | Insufficient
Aripiprazole vs. Placebo | | | | | | | Insufficient
Aripiprazole vs. Placebo | Cardiac Arrhythmia | 3, 453^117, 135, 172^ | 11 | 276 | 8 | 177 | Insufficient
Aripiprazole vs. Placebo | QTcF | 1, 97^135^ | 0 | 47 | 0 | 50 | Insufficient
Aripiprazole vs. Placebo | QTcB | 1, 97^135^ | 3 | 47 | 0 | 50 | Insufficient
Asenapine vs. Placebo | MAE | 2, 709^92, 108^ | 10 | 506 | 6 | 203 | NA
Asenapine vs. Placebo | | | | | | | NA
Asenapine vs. Placebo | MAE limiting treatment | 1, 403^108^ | 1 | 302 | 2 | 101 | NA
Asenapine vs. Placebo
Asenapine vs. Placebo | Mortality | 1, 403^108^ | 0 | 302 | 0 | 101 | Insufficient
Asenapine vs. Placebo | | | | | | | Insufficient
Asenapine vs. Placebo | Diabetes mellitus | 1, 228^92^ | 14 | 151 | 4 | 77 | Insufficient
Asenapine vs. Placebo | | | | | | | Insufficient
Asenapine vs. Placebo | Cardiac Arrhythmias | 2, 631^92, 108^ | 3 | 453 | 0 | 178 | Insufficient
Asenapine vs. Placebo | QT Prolongation | 1, 403^108^ | 0 | 302 | 0 | 101 | Insufficient
Asenapine vs. Placebo | Syncope | 1, 403^108^ | 2 | 302 | 0 | 101 | Insufficient
Olanzapine vs. Placebo | MAE | 1, 161^120^ | 3 | 107 | 0 | 54 | NA
Olanzapine vs. Placebo
Olanzapine vs. Placebo | Mortality | 1, 161^120^ | 0 | 107 | 0 | 54 | Insufficient
Olanzapine vs. Placebo | | | | | | | Insufficient
Olanzapine vs. Placebo | Agranulocytosis and related effects | 1, 161^120^ | 1 | 107 | 0 | 54 | Insufficient
Paliperidone vs. Placebo | MAE | 1, 200^90^ | 4 | 149 | 1 | 51 | NA
Paliperidone vs. Placebo
Paliperidone vs. Placebo | Mortality | 1, 200^90^ | 0 | 149 | 0 | 51 | Insufficient
Paliperidone vs. Placebo | | | | | | | Insufficient
Paliperidone vs. Placebo | NMS | 1, 200^90^ | 0 | 149 | 0 | 51 | Insufficient
Paliperidone vs. Placebo | | | | | | | Insufficient
Paliperidone vs. Placebo | Seizures | 1, 200^90^ | 0 | 149 | 0 | 51 | Insufficient
Paliperidone vs. Placebo | | | | | | | Insufficient
Paliperidone vs. Placebo | Cardiac Arrhythmias | 1, 99^90^ | 0 | 48 | 0 | 51 | Insufficient
Quetiapine vs. Placebo | MAE | 4, 727^72, 109, 115, 119^ | 19 | 447 | 11 | 280 | NA
Quetiapine vs. Placebo | | | | | | | NA
Quetiapine vs. Placebo | MAE limiting treatment | 1, 32^114^ | 1 | 17 | 0 | 15 | NA
Quetiapine vs. Placebo
Quetiapine vs. Placebo | Diabetes mellitus | 2, 475^109, 119^ | 7 | 285 | 0 | 190 | Insufficient
Quetiapine vs. Placebo | | | | | | | Insufficient
Quetiapine vs. Placebo | Cardiac Arrhythmias | 4, 655^72, 109, 114, 119^ | 0 | 375 | 1 | 280 | Insufficient
Quetiapine vs. Placebo | | | | | | | Insufficient
Quetiapine vs. Placebo | Agranulocytosis and related effects | 3, 650^72, 109, 119^ | 12 | 358 | 7 | 265 | Insufficient
Risperidone vs. Placebo | MAE | 8, 856^88, 118, 132, 139, 147, 151, 154, 161^ | 17 | 471 | 8 | 385 | NA
Risperidone vs. Placebo | | | | | | | NA
Risperidone vs. Placebo | MAE limiting treatment | 2, 145^128, 139^ | 2 | 71 | 1 | 74 | NA
Risperidone vs. Placebo
Risperidone vs. Placebo | Mortality | 3, 395^88, 118, 128^ | 0 | 248 | 0 | 147 | Insufficient
Risperidone vs. Placebo | | | | | | | Insufficient
Risperidone vs. Placebo | NMS | 1, 52^125^ | 0 | 26 | 0 | 26 | Insufficient
Risperidone vs. Placebo | | | | | | | Insufficient
Risperidone vs. Placebo | TD | 5, 570^88, 118, 125, 139, 158^ | 0 | 336 | 2 | 234 | Insufficient
Risperidone vs. Placebo | | | | | | | Insufficient
Risperidone vs. Placebo | Cardiac Arrhythmias | 3, 304^139, 151, 158^ | 1 | 145 | 0 | 159 | Insufficient
Risperidone vs. Placebo | | | | | | | Insufficient
Risperidone vs. Placebo | Agranulocytosis and related effects | 1, 101^132^ | 1 | 49 | 0 | 52 | Insufficient
Ziprasidone vs. Placebo | MAE | 3, 548^72, 116, 167^ | 33 | 358 | 11 | 190 | NA
Ziprasidone vs. Placebo | | | | | | | NA
Ziprasidone vs. Placebo | MAE limiting treatment | 2, 311^72, 167^ | 8 | 209 | 1 | 102 | NA
Ziprasidone vs. Placebo
Ziprasidone vs. Placebo | Mortality | 1, 237^116^ | 0 | 149 | 0 | 88 | Insufficient
Ziprasidone vs. Placebo | | | | | | | Insufficient
Ziprasidone vs. Placebo | Cardiac Arrhythmias | 1, 283^72^ | 4 | 193 | 0 | 90 | Insufficient

MAE = major adverse effect; N = number; NA = not applicable; NMS = neuroleptic malignant syndrome; TD = tardive dyskinesia

a Downgraded for ROB.

b Downgraded for ROB and samples size inadequate (<2000).

##### Major AEs During Long-Term (≥ 6 Months) Treatment

Major AEs and major AEs limiting treatment. Two comparisons between aripiprazole and placebo reported on major AEs. Five versus one patient with bipolar disorder experienced a major AE after 30-weeks of treatment with 10- or 30 mg/day of aripiprazole (doses combined for this section) versus placebo, respectively (N = 210).^117^ Fifty-two week placebo-controlled maintenance on aripiprazole 10–30 mg/day was associated with three major AEs in 98 (aripiprazole) and six events in 48 (placebo) patients with schizophrenia.^95^ Luby et al.^129^ compared low-dose risperidone with placebo in 23 preschool-aged children with ASD, none of whom experienced a major AE.

Mortality. Long-term studies reporting mortality rates did not have any deaths for comparisons between placebo and aripiprazole (2 RCTs of bipolar disorder, N = 270),^110, 117^ and placebo with low-dose risperidone (N = 23).^129^

Development of diabetes mellitus. A previously described (SGAs vs. SGAs) retrospective cohort study of the Tennessee Medicaid program compared incidence of type 2 diabetes in patients newly initiated on antipsychotics compared with matched patients not taking antipsychotics for at least 1 year; taking SGAs was associated with an increased risk (HR 2.89; 95% CI 1.64 to 5.10; 25.3 vs. 7.8 cases per 10,000 person-years followup).^193^

Tardive dyskinesia. Rates of tardive dyskinesia were examined in children and adolescent psychiatric patients either receiving SGAs or naïve to antipsychotic treatment for ≥ 6 months; 5 out of 81 and 0 out of 80 patients in these two groups were affected.^201^ A 6-month RCT^157^ (N = 335) of placebo-controlled maintenance on risperidone for treating disruptive, impulse-control, or conduct disorders reported that no patient developed tardive dyskinesia.

Cardiac arrhythmias. One patient taking olanzapine as adjunctive treatment for an eating disorder had a prolonged QT interval during long-term treatment; only four patients had this variable monitored in this observational study with 43 patients taking olanzapine.^163^ An RCT^157^ of 6-month placebo-controlled maintenance treatment with risperidone for disruptive, impulse-control, or conduct disorders reported that one patient receiving risperidone had an abnormal ECG but that no patient had a clinically significant change in QT interval.

##### General AEs During Short- and Long-Term Treatment

Table 38 includes findings for any AE limiting treatment during all timepoints. Tables 39 and 40 contain a summary of the findings for other general AEs where there was at least low SOE in studies comparing SGAs with placebo over short and long durations, respectively. The major reason we deemed outcomes as having insufficient SOE was imprecision from small samples in situations of rare events. Despite a large sample (21 studies, 2009 patients), the short-term outcome of hyperprolactinemia was graded as having insufficient SOE across all SGAs because of inconsistency; for example, comparisons between olanzapine and placebo clearly favored placebo, while studies of aripiprazole found serum prolactin levels to reduce for treatment groups relative to placebo. Other outcomes graded as having insufficient SOE due to ROB and imprecision include akathisia for aripiprazole comparisons (7 studies, 1325 patients, 5% event rate in placebo group; RR, 0.86; 95% CrI, 0.31 to 2.149), and sedation for risperidone (4 studies, 408 patients; RR, 2.58; 95% CrI, 0.70 to 14.89) and ziprasidone (2 studies, 264 patients; not pooled but 95% CI limits between 0.73 and 13.98).

Table 38 Findings for adverse effects limiting treatment in short- and long-term comparisons between SGAs and placebo

Comparison | Duration | N Studies, N Patients | SGA Events | SGA N | Placebo Events | Placebo N | Relative Effects^a^, Studies
All SGAs vs. placebo | <6 mo | 24, 4043 | 183 | 2644 | 65 | 1399 | RR, 1.47; 95% CrI, 1.05 to 2.13 ^71, 72, 73, 88, 90, 92, 106, 108, 109, 114, 116–120, 127, 128, 131, 135, 151, 155, 156, 167, 170^
All SGAs vs. placebo | | 5, 348 | 0 | 168 | 0 | 180 | Not estimable^115, 123, 132, 153, 158^
All SGAs vs. placebo
All SGAs vs. placebo | 6–12 mo | 3, 584 | 14 | 146 | 0 | 64 | RR, 12.82; 95% CI, 0.78 to 211.72^117^
All SGAs vs. placebo | | | 2 | 172 | 1 | 163 | RR, 1.90; 95% CI, 0.17 to 20.70^157^
All SGAs vs. placebo | | | 0 | 19 | 0 | 20 | Not estimable^134^
All SGAs vs. placebo
All SGAs vs. placebo | 12+ mo | 3, 266 | 0 | 30 | 0 | 30 | Not estimable^110^
All SGAs vs. placebo | | | 1 | 98 | 1 | 48 | RR, 0.49; 95% CI, 0.03 to 7.66^95^
All SGAs vs. placebo | | | 1 | 31 | 1 | 29 | RR, 0.94; 95% CI, 0.06 to 14.27^86^
Aripiprazole vs. placebo | <6 mo | 5, 969 | 46 | 680 | 12 | 371 | RR, 1.91; 95% CrI, 0.82 to 4.65^73, 106, 117, 131, 135^
Aripiprazole vs. placebo | | 1, 82 | | | | | Not estimable^123^
Aripiprazole vs. placebo
Aripiprazole vs. placebo | 6–12 mo | 1, 210 | 14 | 146 | 0 | 64 | RR, 12.82; 95% CI, 0.78 to 211.72^117^
Aripiprazole vs. placebo
Aripiprazole vs. placebo | 12+ mo | 2, 206 | 0 | 30 | 0 | 30 | Not estimable^110^
Aripiprazole vs. placebo | | | 1 | 98 | 1 | 48 | RR, 0.49; 95% CI, 0.03 to 7.66^95^
Asenapine vs. placebo | <6 mo | 2, 709 | 17 | 302 | 4 | 101 | RR, 1.42; 95% CI, 0.49 to 4.13 ^108^
Asenapine vs. placebo | | | 14 | 204 | 3 | 102 | RR, 2.33; 95% CI, 0.69 to 7.94^92^
Lurasidone vs placebo | <6 mo | 1, 149 | 4 | 100 | 5 | 49 | RR, 0.39; 95% CI, 0.11 to 1.40^127^
Olanzapine vs. placebo | <6 mo | 1, 161 | 3 | 107 | 1 | 54 | RR, 1.51; 95% CI, 0.16 to 14.21^120^
Olanzapine vs. placebo
Olanzapine vs. placebo | 12+ mo | 1, 60 | 1 | 31 | 1 | 29 | RR, 0.94; 95% CI, 0.06 to 14.27^86^
Paliperidone vs. placebo | <6 mo | 1, 200 | 3 | 149 | 0 | 51 | RR, 2.43; 95% CI, 0.13 to 46.19 ^90^
Quetiapine vs. placebo | <6 mo | 5, 748 | 38 | 458 | 19 | 290 | RR, 1.21; 95% CrI, 0.30 to 4.73^155, 114, 109, 119, 72^
Quetiapine vs. placebo | | 1, 30 | | | | | Not estimable^115^
Risperidone vs. placebo | <6 mo | 6, 559 | 25 | 325 | 7 | 234 | RR, 1.97; 95% CrI, 0.71 to 5.92^151, 156, 128, 118, 88, 170^
Risperidone vs. placebo | | 3, 239 | | | | | Not estimable^153, 158, 132^
Risperidone vs. placebo
Risperidone vs. placebo | 6–12 mo | 2, 374 | 2 | 172 | 1 | 163 | RR, 1.90; 95% CI, 0.17 to 20.70^157^
Risperidone vs. placebo | | | 0 | 19 | 0 | 20 | Not estimable^134^
Ziprasidone vs. placebo | <6 mo | 3, 548 | 33 | 358 | 14 | 190 | RR, 1.36; 95% CrI, 0.37 to 6.34^116, 71, 167^

CI = confidence interval; CrI = credible interval; m =month; N = number; RR = risk ratio; SGA = second-generation antipsychotic

a RR above 1.0 indicate more harm from SGA. We did not combine data from 1 or 2 studies so these results are always presented separately.

Table 39 Summary of findings for general adverse effects: Short-term durations of comparisons between SGAs and placebo

Comparison | Outcome | N Studies, N Patients | SGA Events | SGA N | Placebo Events | Placebo N | Relative Effects^a^, Studies | Strength of Evidence; Conclusions
All SGAs vs. placebo | Any EPS | 15, 2730 | 233 | 1757 | 40 | 973 | RR, 2.94; 95% CI, 2.02 to 4.27^71–73, 88, 93, 117–119, 121, 123, 131, 139, 151 {Snyder, 2002 #117^, ^172^ | Moderate; SGAs probably increase risk^b^
All SGAs vs. placebo | | 2, 32 | 0 | 17 | 0 | 15 | Not estimable^114, 170^
All SGAs vs. placebo
All SGAs vs. placebo | Akathisia | 21, 3638 | 151 | 2433 | 56 | 1205 | RR, 1.29; 95% CrI, 0.81 to 2.27^71, 73, 76, 88, 90, 92, 108, 116–118, 120, 121,127, 128, 131, 135, 142, 154, 155, 167, 172^ | Low; may make little or no difference ^c^
All SGAs vs. placebo
All SGAs vs. placebo | Weight (kg) | 37, 3919 | - | 2384 | - | 1535 | MD, 1.48; 95% CI, 1.06 to 1.91^71–72, 76, 86, 90, 109, 111, 114–121, 123, 125–128, 131, 132, 135, 139, 147, 151–156, 158, 167, 172, 178, 192^ | Moderate; SGAs probably increase slightly^b^
All SGAs vs. placebo
All SGAs vs. placebo | BMI (kg·m^−2^) | 16, 2462 | - | 1582 | - | 880 | MD, 0.61; 95% CI, 0.38 to 0.85^73, 76, 108, 111, 114, 117, 118, 120, 127, 128, 131, 135, 153, 157, 158, 172^ | Moderate; SGAs probably increase slightly^b^
All SGAs vs. placebo
All SGAs vs. placebo | ≥ 7% increase in weight | 17, 3057 | 337 | 2023 | 42 | 1034 | RR, 3.53; 95% CrI, 2.49 to 5.23^72, 73, 76, 86, 90, 92, 108, 109, 117–120, 123, 126, 131, 135, 178^ | Moderate; SGAs probably increase risk^b^
All SGAs vs. placebo
All SGAs vs. placebo | Increased total cholesterol | 6, 643 | 92 | 410 | 13 | 233 | RR, 3.17; 95% CrI, 1.29 to 9.13^114, 117, 119, 120, 135, 192^ | Low; SGA may increase risk^d^
All SGAs vs. placebo | Increased total cholesterol | 1, 218 | 0 | 52 | 0 | 166 | Not estimable^87, 131^
All SGAs vs. placebo
All SGAs vs. placebo | Increased triglycerides | 10, 1383 | 130 | 897 | 38 | 486 | RR, 1.64; 95% CrI, 1.09 to 2.63^72, 76, 114, 117, 119, 120, 131, 135, 147, 192^ | Moderate; SGAs probably increase risk^b^
All SGAs vs. placebo
All SGAs vs. placebo | Sedation | 21, 2710 | 288 | 1696 | 79 | 1014 | RR, 2.19; 95% CrI, 1.50 to 3.41^72, 77, 93, 109, 114–119, 126,127, 128, 131, 135, 147, 155, 156, 162, 167, 172^ | Moderate; SGA probably increase risk^b^
All SGAs vs. placebo
All SGAs vs. placebo | Somnolence | 26, 3942 | 560 | 2481 | 119 | 1461 | RR, 2.91; 95% CrI, 2.27 to 3.86^71–73, 76, 86, 88, 90, 92, 109, 116–119, 121, 127, 128, 131, 132, 135, 139, 151, 153, 154, 158, 167, 172^ | Moderate; SGAs probably increase risk^b^
Aripiprazole vs. placebo | Any EPS | 6, 1000 | 117 | 655 | 17 | 345 | RR, 3.10; 95% CrI, 1.26 to 7.01^73, 117, 121, 123, 131, 172^ | Low; Aripiprazole may increase risk^e^
Aripiprazole vs. placebo
Aripiprazole vs. placebo | Weight (kg) | 7, 1042 | - | 647 | - | 395 | MD, 0.98; 95% CrI, 0.54 to 1.48^73, 117, 121, 123, 1231, 135, 172^ | Moderate; Aripiprazole probably increases slightly^b^
Aripiprazole vs. placebo
Aripiprazole vs. placebo | BMI (kg·m^−2^) | 5, 881 | - | 587 | - | 294 | MD, 0.33; 95% CI, 0.07 to 0.67^73, 117, 131, 135, 172^ | Moderate; Aripiprazole probably increases slightly^b^
Aripiprazole vs. placebo
Aripiprazole vs. placebo | ≥ 7% increase in weight | 5, 991 | 93 | 647 | 15 | 344 | RR, 3.01; 95% CrI, 1.33 to 7.10^73, 117, 123, 131, 135^ | Low; Aripiprazole may increase^e^
Aripiprazole vs. placebo
Aripiprazole vs. placebo | Somnolence | 6, 1012 | 119 | 661 | 29 | 351 | RR, 2.73; 95% CrI, 1.24 to 7.65^73, 117, 121, 131, 135, 172^ | Low; Aripiprazole may increase risk^e^
Olanzapine vs. placebo | Weight (kg) | 4, 337 | - | 215 | - | 122 | MD, 3.96; 95% CI, 2.31 to 6.34^76, 86, 120, 127^ | Moderate; Olanzapine probably increases^b^
Olanzapine vs. placebo
Olanzapine vs. placebo | BMI (kg·m^−2^) | 2, 267 | - | 107 | - | 54 | MD, 1.16; 95% CI, 0.93 to 1.39^120^ | Moderate; Olanzapine probably increases^b^
Olanzapine vs. placebo | | | - | 72 | - | 34 | MD, 1.50; 95% CI, 1.06 to 1.94^76^ | Moderate; Olanzapine probably increases^b^
Olanzapine vs. placebo
Olanzapine vs. placebo | ≥ 7% increase in weight | 4, 337 | 99 | 215 | 8 | 122 | RR, 6.08; 95% CrI, 1.84 to 27.06^76, 86, 120, 126^ | Low; Olanzapine may increase risk^e^
Olanzapine vs. placebo
Olanzapine vs. placebo | Hyperprolactinemia | 2, 268 | 50 | 107 | 1 | 54 | RR, 25.53; 95% CI, 3.58 to 177.76^120^ | Low; Olanzapine may increase risk^e^
Olanzapine vs. placebo | | | 58 | 72 | 6 | 35 | RR, 4.70; 95% CI, 2.25 to 9.82^76^
Quetiapine vs. placebo | Weight (kg) | 6, 778 | - | 473 | - | 305 | MD, 1.44; 95% CI, 0.60 to 2.31^72, 109, 114, 115, 119, 155^ | Moderate; Quetiapine probably increases slightly^b^
Quetiapine vs. placebo
Quetiapine vs. placebo | Sedation | 6, 778 | 90 | 473 | 32 | 305 | RR, 1.67; 95% CrI, 0.77 to 3.87^72, 109, 114, 115, 119, 155^ | Low; may make little or no difference ^c^
Quetiapine vs. placebo
Quetiapine vs. placebo | Somnolence | 3, 697 | 106 | 432 | 18 | 265 | RR, 2.95; 95% CrI, 0.92 to 8.62^72, 109, 119^ | Low; may make little or no difference ^c^
Risperidone vs. placebo | Any EPS | 5, 636 | 52 | 365 | 13 | 271 | RR, 2.78; 95% CrI, 1.27 to 6.50^88, 118, 139, 151, 158^ | Low; Risperidone may increase risk^e^
Risperidone vs. placebo
Risperidone vs. placebo | Weight (kg) | 14, 929 | - | 522 | - | 475 | MD, 1.52; 95% CI, 0.78 to 2.29^111, 118, 125, 128, 132, 139, 147, 151–154, 156, 158, 178^ | Moderate; Risperidone probably increases slightly^b^
Risperidone vs. placebo
Risperidone vs. placebo | BMI (kg·m^−2^) | 6, 730 | - | 397 | - | 333 | MD, 0.68; 95% CI, 0.27 to 1.18^111, 118, 128, 153, 157, 158^ | Moderate; Risperidone probably increases slightly^b^
Risperidone vs. placebo
Risperidone vs. placebo | Somnolence | 9, 862 | 163 | 473 | 43 | 389 | RR, 3.25; 95% CrI, 1.96 to 5.94^128, 132, 151, 153, 154, 158, 88, 118, 139^ | Moderate; Risperidone probably increases risk slightly^b^
Ziprasidone vs. placebo | Weight (kg) | 3, 360 | - | 246 | - | 114 | MD, −0.10; 95% CI, −1.34 to 1.13^71, 116, 167^ | Moderate; probably makes little or no difference ^b^
Ziprasidone vs. placebo
Ziprasidone vs. placebo | Somnolence | 3, 548 | 76 | 358 | 13 | 190 | RR, 2.97; 95% CrI, 0.84 to 9.96^71, 116, 167^ | Low; may make little or no difference ^c^

AE = adverse effect; BMI = body mass index; CI = confidence interval; CrI = credible interval; kg = kilogram; m = meter; MD = mean difference; N = number; RR = risk ratio; SGA = second-generation antipsychotic

a Risk ratios above 1.0 and positive MD favor placebo.

b Downgraded for ROB.

c Downgraded for ROB and imprecision because point estimate and CrI includes clinically significant favor for placebo.

d Downgraded for ROB and inconsistency.

e Downgraded for ROB and imprecision, based on small sample size.

##### General AEs During Long-Term (≥ 6 Months) Treatment

Table 40 Summary of findings for general adverse effects: Long-term durations of SGAs versus placebo

Comparison | Outcome, Duration | N Studies, N Patients | Relative Effects^a^, Studies | Strength of Evidence; Conclusions
Risperidone vs. placebo | Weight (kg), 6 to <12mo | 4, 467 | MD, 2.86; 95% CrI, −1.22 to 7.42^129, 134, 157, 199^ | Low; may make little or no difference^b^
Risperidone vs. placebo | BMI (kg·m^−2^), 6 to <12mo | 2, 405 | MD, 0.70; 95% CI, 0.49 to 0.91^157^ MD, 1.80; 95% CI, −0.61 to 4.21^199^ | Low; may make little or no difference^b^

BMI = body mass index; CI = confidence interval; CrI = credible interval; kg = kilogram; m = meter; MD = mean difference; N = number; RR = risk ratio; SGA = second-generation antipsychotic

a Positive MD favors placebo. We did not combine data from 1 or 2 studies so these results are always presented separately.

b Downgraded for ROB and imprecision because CrI includes clinically significant favor for placebo.

### KQ 2a and b Between- and Within-Study Subgroup Effects

This section presents findings from between-study and within-study analyses for subgroup effects. Table 41 includes the findings for between-study findings based on meta-regression analyses we conducted, and Table 42 includes the findings from a wide range of within study subgroup analyses. Figures 82 to 85 present plots of data used for the meta-regressions and for observations on whether harm key outcomes differed by condition of diagnosis. Key findings are followed by detailed analyses. Appendix G includes the model structure and code for the meta-regressions.

Table 41 Coefficient variables from univariate meta-regressions for the effects of subgroup variables on key harm outcomes in SGA versus placebo comparisons across conditions

Outcome | Subgroup Variable
Outcome | Age (Mean Age in Years) | Sex (% Male) | Treatment Naïve (%) | Treatment Duration (Weeks)
Weight (kg) | 0.012 (95% CrI, −0.13 to 0.16) | 0.013 (95% CrI, −0.013 to 0.040) | −0.0009 (95% CrI, −0.019 to 0.017) | 0.043 (95% CrI, 0.015 to 0.072)^*^
≥ 7% increase in weight | 0.045 (−0.11 0.21) | 0.0017 (−0.024, 0.026) | 0.0089 (−0.006, 0.025) | 0.0043 (−0.067, 0.067)
Somnolence | −0.010 (−0.01, 0.08) | 0.032 (−0.02, 0.09) | 0.002 (−0.005, 0.010) | −0.005 (−0.07, 0.06)
EPS Symptoms | 0.029 (−0.09, 0.15) | −0.012 (−0.04, 0.01) | 0.006 (−0.01, 0.02) | 0.018 (−0.06, 0.10)

kg = kilograms

* Statistically significant

Table 42 Within-study analyses for subgroups of interest: Harms

First Author, Year, Comparison | Type of Analysis | Outcome | Authors’ Conclusions
FGA vs FGA
Sallee, 1997^168^ Haloperidol vs. pimozide vs. placebo | Sex | Prolactin | No significant differences were found in prolactin levels by sex.
Sallee, 1997^168^ Haloperidol vs. pimozide vs. placebo | Dose | EPS Symptoms | For pimozide, drug dose associated with EPS. Pimozide >2 mg/day exhibited EPS. 1–2 mg/day EPS in 10%; >2 mg/day EPS in 69%. For haloperidol, EPS not dose related.
FGA vs SGA
Bruggeman, 2001^164^ Pimozide vs. risperidone | Age | Weight | Patients <18 years had more weight gain than patients ≥18 years in the risperidone group, however this was not significant. Weight gain was comparable across age groups in the pimozide-treated patients.
Ratzoni, 2002^99^ Haloperidol vs. olanzapine vs. risperidone | Sex, treatment history, illness duration, dose, baseline weight, parental BMI, concern about weight gain, history of diet | Weight | Patients with lower baseline weight showed a significantly greater increase in weight. Paternal, but not maternal, BMI was significantly correlated with patient weight gain. Weight gain ≥7% occurred more frequently among males than females (nonsignificant). History of dieting, previous antipsychotic use, medication dose and duration of illness were not associated with weight gain. Drug-naïve patients did not gain more weight than those on previous antipsychotics.
Ratzoni, 2002^99^ Haloperidol vs. olanzapine vs. risperidone | Sex, treatment history, illness duration, dose, baseline weight, parental BMI, concern about weight gain, history of diet | BMI | Among patients who showed concerned about weight gain, males showing an increase in BMI, but females did not.
Wudarsky, 1999^99^ Clozapine vs. haloperidol vs. olanzapine | Sex | Prolactin | In patients receiving clozapine, females had significantly elevated prolactin levels than males. There was no significant sex difference in patients receiving haloperidol or olanzapine.
SGA vs SGA
Arango, 2014^181^ Risperidone vs. Olanzapine vs. Quetiapine | Age | Glucose | The younger group of patients (below the age of 12 years) showed a significant increase in glucose in comparison to the older group (p < .0001).
Arango, 2014^181^ Risperidone vs. Olanzapine vs. Quetiapine | Drug naive | Dyskinesia | Drug naïve patients had significant increases in dyskinesia than non-naïve patients. Drug naïve patients who were taking risperidone showed more dyskinesia than naïve patients on olanzapine or quetiapine.
Arango, 2014^181^ Risperidone vs. Olanzapine vs. Quetiapine | Age, drug naïve and dose | Parkinsonism | Patients on higher doses of risperidone, olanzapine and quetiapine (p<0.001) and older patients (p <0.001) had more parkinsonism than patients on lower doses and who were younger. Risperidone and olanzapine drug naïve patients had signficiantly higher parkinsonism than Quetiapine naïve patients.
Arango, 2014^181^ Risperidone vs. Olanzapine vs. Quetiapine | Age and antipsychotic exposure | TD | Older patients, patients with longer exposure to antipsychotics and drug naïve patients had a higher risk of developing TD.
Arango, 2014^181^ Risperidone vs. Olanzapine vs. Quetiapine | Drug naïve | Akathisia | There was no difference of akathisia between naïve and non-naïve patients.
Castro-Fornieles, 2008^101^ Quetiapine vs Risperidone vs Olanzapine | Sex and age | BMI | Significant differences were found between sex and BMI increase, males presented a mean increase of 3.77 and females a mean increase of 1.34. Age was not significantly correlated with BMI increase.
Crocq, 2007^69^ Olanzapine vs. risperidone | Sex | Weight and BMI | Weight and BMI increase was consistently but not statistically greater in girls than boys in all treatment groups.
Cuerda, 2011^184^ Risperidone vs. Olanzapine vs. Quetiapine | Sex | Weight gain, waist circumference | Weight gain was not different in males and females (p = 0.57), nor were there differences in the changes in waist circumference ( p = 0.93) or body composition (p = 0.07) between genders.
Findling, 2008a^73^ Low- vs. high-dose aripiprazole | Ethnicity, age and gender | Somnolence | Black patients reported substantially higher rates (35% in the 10 mg arm and 55% in the 30 mg arm) than the overall population (12% in the 10 mg arm and 22% in the 30 mg arm) but this trend appeared to be only observed in the short-term study. No differences were noted in incidence stratified by age or gender.
Haas, 2009a^74^ Low- vs. high-dose risperidone | Sex and age | Prolactin | The emergence of prolactin-related adverse events was higher in adolescent females than males.
Haas, 2009b^88^ Low- vs. high-dose risperidone | Sex | Prolactin | Mean change in prolactin levels were higher in females than males.
Wink, 2014^144^ Risperidone vs. aripiprazole | Analysis of covariance by intellectual disability (aripiprazole only) | BMI-z | Positive association between BMI-z score and persons with intellectual disability; slightly negative association in persons without intellectual disability.
SGA vs Placebo Aripiprazole
Findling, 2009^117^ Low- vs. high-dose aripiprazole vs. placebo | Sex | Prolactin | Decreases in prolactin levels were more pronounced for males than for females.
Tramontina, 2009^121^ Aripiprazole vs. placebo | Age | Weight/BMI | There was no significant difference between patients ≤10 and >10 years of age for any primary outcome measure.
SGA vs Placebo Risperidone
Aman, 2004^149^ Risperidone (with and without stimulants) vs placebo (with and without stimulants) | Stimulant vs no stimulant | Weight | Children taking stimulants gained as much weight as those not receiving stimulants (p=0.42), interaction term), irrespective of combined use with risperidone or placebo.
Aman, 2004^149^ Risperidone (with and without stimulants) vs placebo (with and without stimulants) | Stimulant vs no stimulant | AE | There appeared to be a numerical trend for less somnolence (p=0.26), fewer headaches (p=0.29) and less vomitting (p=0.32) in patients with stimulant.
Aman, 2002^151^ Risperidone vs. placebo | Sex | Prolactin | Males had a significantly greater increase in prolactin levels on risperidone than placebo, whereas increase in mean prolactin levels was not significant for females.
Haas, 2009c^118^ Low- vs. high dose risperidone vs. placebo | Age | AE | The type and rate of AEs were generally similar between risperidone-treated patients ≤12 or >12 years. For the low dose risperidone, patients >12 years experienced slightly higher rates of somnolence and headache.
Haas, 2009c^118^ Low- vs. high dose risperidone vs. placebo | Sex | Prolactin | A greater proportion of females had above pathological limits in prolactin levels at endpoint.
Haas, 2009c^118^ Low- vs. high dose risperidone vs. placebo | Dose | Somnolence | There was a dose dependent increase in the percentage of riperidone-treated subjects who experienced somnolence or fatigue.
Martin, 2000^197^ Risperidone vs control | Sex, ethnicity and age | Weight z scores and 7% weight gain | Baseline demographic and clinical characteristics (age, gender, pubertal status, ethnicity, baseline BMI, discharge diagnosis, concurrent medication use) were not associated with an increase likelihood to gain weight morbidly.
McCracken, 2002^132^ Risperidone vs. placebo | Age, dose, sex, IQ, site, weight, initial leptin change | Weight | None of the variables or combinations of the variables listed were predictors of weight gain.
McCracken, 2002^132^ Risperidone vs. placebo | Age, baseline BMI, caloric intake | BMI | There was no significant effect of age, baseline BMI or caloric intake on BMI z-score.
Reyes, 2006^157^ Risperidone vs placebo | Sex, age, diagnosis, disease severity | Risk for symptom recurrance | Sex, age, diagnosis and baseline disruptive behavior severity did not affect risk for symptom recurrence.
Reyes, 2006^157^ Risperidone vs placebo | Age | Weight, AE | Weight gain was reported more frequently in children <12 years of age than those ≥12 years; however this trend was not significant. Other AEs were comparable between age groups.
Reyes, 2006^157^ Risperidone vs placebo | Sex | Prolactin | Females experienced greater increase in prolactin levels than males.
Snyder, 2002^158^ Risperidone vs. placebo | Comorbidity, cotreatment, treatment history, condition, sex | Weight | Cotreatment with psychostimulant had no impact on weight. Mean weight increase was similar between patients who were risperidone-naïve and those previously treated.
Snyder, 2002^158^ Risperidone vs. placebo | Comorbidity, cotreatment, treatment history, condition, sex | Prolactin | Risperidone-naïve patients had significantly lower prolactin levels than those previously treated with risperidone at extension study entry. Risperidone associated with significant increases in prolactin in both girls and boys
Snyder, 2002^158^ Risperidone vs. placebo | Comorbidity, cotreatment, treatment history, condition, sex | Sedation | Sedation increased among risperidone-naïve patients, but not among previously treated patients.
SGA vs Placebo Quetiapine
Pathak, 2013^119^ Low- vs. high dose quetiapine vs. placebo | Age, sex and cotreatment | AE | Most common AEs (increased appetite and tachycardia) occurred more frequently in quetiapine-treated patients in the 10–12 year age group compared with older patients (aged 13 – 17 years). The incidence of individual common AEs (nausea, dizziness, sedation and increaded appetitie) was higher in concomitant psychostimulant users in the high-dose quetiapine group.
Pathak, 2013^119^ Low- vs. high dose quetiapine vs. placebo | | Prolactin | A greater proportion of males had changes in prolactin levels than females.
Multiple Comparisons
Bobo, 2013^193^ SGA users vs. controls | Dose | Diabetes | Risk for type 2 diabetes for SGA antipsychotics and risperidone increased with cumulative dose. SGA (HR=2.89 [95% CI=1.64–5.10]), risperidone [HR=2.20[95% CI=1.14–4.26]).
Correll, 2009^183^ SGA | Dose | Body composition | Antipsychotic dose was not associated with body composition parameters changes in patients receiving aripiprazole, olanzapine, or quetiapine. With risperidone, does >1.5 mg/day were associated with greater increases in weight (p<0.0001), waist (p=0.001), fat mass (p<0.05), and BMI z-score (p<0.05).
Correll, 2009^183^ SGA | Dose | Metabolic effects | Metabolic effects did not differ by dose in groups taking aripiprazole or quetiapine. Significantly greater increases in several metabolic parameters were observed in patients treated with doses >10 mg/day of olanzapine (total cholesterol (p<0.01) and glucose (p<0.05)) and doses >1.5 mg/day of risperidone (total cholesterol (p<0.01) and triglycerides (p<0.01)).
Correll, 2009^183^ SGA | Stimulant vs no stimulant | Weight, metabolic effects, AEs | Body composition, glucose and lipid parameters, and prolactin were not significantly different among patients co-treated with or without stimulants (p values,0.13–0.99). Discontinuation rates for intolerability were similar between patients without versus with stimulant co-treatment. (7.4% vs 4.2%, p=0.50)
Jerrell, 2008^196^ Antipsychotics cohort | Sex, age, race and multiple antipsychotic use. | Weight gain | The odds of being diagnosed with incident obesity/excessive weight gain being higher for females (p= <0.0001), adolescents 13 and over (p=0.0001), and those taking multiple antipsychotic medications (p=<0.0001), but lower for African Americans (p= 0.01).
Jerrell, 2008^196^ Antipsychotics cohort | Sex, age, race and multiple antipsychotic use. | Diabetes and dyslipidemia | The odds of developing the metabolic conditions of Type II diabetes and dyslipidemia being higher for females (p=<0.00001), those taking multiple antipsychotic medications (p=0.001), and adolescents 13 and over (p= <0.00001).
Jerrell, 2008^196^ Antipsychotics cohort | Sex, age, race and multiple antipsychotic use. | Cardiovascular, cerebrovascular and hypertension | The odds of developing cardiovascular conditions being higher for pediatric clients (p=0.99) and taking multiple antipsychotic medications (p=0.02).
Jerrell, 2008^196^ Antipsychotics cohort | Sex, age, race and multiple antipsychotic use. | EPS, somnolence/sedation, agitation, blurred vision | The odds of developing these problems (e.g., EPS, somnolence/sedation, agitation, blurred vision) were higher for females (p=0.004), and those taking multiple antipsychotics (p=<0.00001)..
Wonodi, 2007^201^ Antipsychotic treatment ≥6 mo vs. Antipsychotic naive | Ethnicity, psychostimulants, antidepressants and mood stabilizers | TD | Results were mostly driven by rates in African–American patients. 5 of 44 (11%) of this African–American subgroup (atypicals only) exhibited TD compared with 0 of 55 antipsychotic-naïve subjects (p=0.015, Fisher’s exact test). Rates of TD were much lower in the European American group and comparison group: 0 of 34 (0%) atypical agents, 0 of 23 (0%) comparison group. The rates of TD in this “non-psycho-stimulant” subgroup were similar to the 16% rate observed in the larger treated group: three of 20 (15%) atypicals-only exhibited TD. Among patients never treated with antidepressants, two of 16 (12%) atypicals-only exhibited TD. Similar rates were observed in the sample not treated with mood-stabilizers: two of 25 (8%) on only atypicals displayed TD.

AEs = adverse effects; BMI = body mass index; EPS = extrapyramidal symptoms; HR = hazard ratio; IQ = intelligence quotient; mg = milligrams; mo = months; SGA = second-generation antipsychotic; TD = tardive dyskinesia

Figure 82 Plot of data for weight change (kilograms) at longest followup for comparisons between SGAs and placebo

ADHD/DICD = attention deficit hyperactivity disorder, and disruptive, impulse-control, and conduct disorders; ASD = autism spectrum disorders; BI = behavioral issues outside of diagnosis; BD = bipolar disorder; M = mixed conditions; SZ = schizophrenia; TD = tic disorders

Figure 82 displays the plot of data for 42 studies for weight change in kilograms for comparisons between SGAs and placebo at the longest available followup. This data was used for meta-regression analysis by condition, as per description on page 157.

Figure 83 Plot of data for weight increase of 7 percent or greater at longest followup for comparisons between SGAs and placebo

ASD = autism spectrum disorders; BI = behavioral issues outside of diagnosis; BD = bipolar disorder; M = mixed conditions; SZ = schizophrenia

Figure 83 displays the plot of data for 19 studies for body weight increase of 7% or greater at longest followup between SGAs and placebo. This data was used for meta-regression analysis by condition, as per description on page 157.

Figure 84 Plot of data for proportion of patients reporting of somnolence at longest followup for comparisons between SGAs and placebo

ADHD/DICD = attention deficit hyperactivity disorder, and disruptive, impulse-control, and conduct disorders; ASD = autism spectrum disorders; BD = bipolar disorder; SZ = schizophrenia; TD = tic disorders

Figure 84 displays the plot of data for proportion of patients in 28 studies who reported somnolence at the longest available followup, comparing SGAs and placebo. This data was used for meta-regression analysis by condition, as per description on page 157.

Figure 85 Plot of data for proportion of patients with EPS symptoms (akathisia, any EPS, and dystonia combined) at longest followup for comparisons between SGAs and placebo

ADHD/DICD = attention deficit hyperactivity disorder, and disruptive, impulse-control, and conduct disorders; ASD = autism spectrum disorders; BD = bipolar disorder; SZ = schizophrenia; TD = tic disorders

Figure 85 displays the plot of data for proportion of patients in 35 studies with EPS symptoms, made up of akathisia, any EPS, and dystonia combined, at the longest available followup for SGAs compared to placebo. This data was used for meta-regression analysis by condition, as per description on page 157.

#### Key Points: Between-Study Subgroup Effects

- Meta-regressions were conducted for comparisons between SGAs and placebo/no treatment to determine if effects on four outcomes (weight change, proportion gaining 7% or more weight, somnolence, and EPS symptoms) were influenced by four subgroup variables (mean age, % male, % treatment naïve, and treatment duration). The only analysis with statistically significant findings was for treatment duration on weight change. Small increases of weight gain were seen for longer treatment duration (0.043 kg per week).
- Treatment duration was added as a study-level variable into the network meta-analyses for weight and BMI; although this variable was shown to statistically modify effects for BMI the results of either network meta-analysis were not changed to any meaningful extent.
- There did not appear to be any variable effects for the four harm outcomes (weight change, gaining 7% or more weight, somnolence, and EPS symptoms) across diagnostic conditions; harms appeared to occur to a similar magnitude in different conditions regardless of the typical dose used.

#### Key Points: Within-Study Subgroup Effects

- Twenty-six studies reported on subgroup analyses. Findings were often inconsistent on whether there are any moderating effects by various subgroup variables on harms.
- Body composition, fasting glucose, and prolactin elevations do not appear to differ in patients taking SGAs based on concurrent use of psychostimulants.
- Dose of SGAs—particularly when considering cumulative doses—was found in two large observational studies to increase the risk for metabolic effects including increased glucose levels and development of diabetes.
- Risperidone appears to increase serum prolactin more in females than males; few studies reported on other subgroup variables for this harm.
- Findings for effect moderation on risk for somnolence and neuromotor effects were mainly from single studies.

#### Detailed Analysis

##### Between-Study Subgroup Effects: Analyses for Key Subgroup Variables

We performed univariate meta-regression analyses on four key harm outcomes (weight, greater than 7% increase in weight, somnolence, and EPS symptoms) for the variables of age, sex, previous antipsychotic exposure, and treatment duration. Data from all followup durations for SGA versus placebo comparisons was used in order to maximize clinical relevance and include as many studies as possible; for studies with more than one followup timepoint we used data from the longest timepoint. For the outcome of EPS symptoms, we included data from findings on (in hierarchical order) akathisia, dystonia, and any EPS. The subgroup variables used were chosen because most studies reported on these variables and because of their relevance across conditions; other variables of interest included concomitant medication use, comorbidities, and phase of disorder, although these were considered either too complex to capture (e.g., in many cases of multiple comorbidities) or too condition specific (i.e., phase of disorder).

Table 41 presents the results (coefficient variable and 95% CrI) generated for each variable. The only finding that was statistically significant was for slightly greater weight changes over longer treatment durations (0.043 kg per week of additional treatment).

Because of the results showing treatment duration as a potential effect modifier for weight gain, this variable was added into the network meta-analyses for weight and BMI; although treatment duration was shown to statistically modify effects for BMI (i.e., regression coefficient β=0.55; 95% CrI, 0.09 to 1.91) the results of the network meta-analysis were not changed to any meaningful extent.

One of our subgroups for this KQ was in relation to treatment condition. Figures 82 to 85 present the data used for our meta-regressions, with each study identified by the condition it studied. Based on observations on these plots, we could not see any trends indicating the effects varied by condition. The results for conditions for which these drugs are typically used in lower doses (e.g., ADHD) than for other conditions (e.g., schizophrenia) appear to be very similar when looking across studies.

##### Between-Study Subgroup Effects: Analyses for Key Subgroup Variables

Twenty-six studies reported subgroup analysis for various variables of interest. A summary of the results by outcome is presented below; Table 42 provides details for the results by drug comparison and study.

Body composition. Thirteen studies examined how age (N = 6), gender (N = 6), ethnicity (N = 2), treatment history (N = 2), dose (N = 4), and/or concurrent medication use (N = 3) influenced weight gain during treatment with antipsychotics. No significant findings for age were found in trials of risperidone^131, 132, 157, 164^ and aripiprazole,^121^ or in a prospective cohort of children and adolescents taking risperidone, quetiapine, or olanzapine.^101^ Obesity/excessive weight gain was significantly greater in children ages 13 and over versus younger than 13 when treated with haloperidol and various SGA (p < 0.0001).^196^ Findings for sex were conflicting. Haloperidol, olanzapine, and risperidone appeared to cause weight gain of 7 percent or more body weight more often in males than females but findings were not significant;^99^ quetiapine, risperidone and olanzapine significantly increased in BMI only for males in one study.^101^ Two studies reported greater weight gain in females than males taking olanzapine and risperidone (p > 0.5),^69^ or haloperidol and various SGAs (p < 0.0001).^101^ Two cohort studies found no difference between sex and weight gain for children taking risperidone, olanzapine, or quetiapine^182^ and risperidone.^199^ Ethnicity was not associated with weight gain in patients on risperidone.^199^ Weight gain was lower in African Americans taking haloperidol or various SGAs (p = 0.01).^196^

Three studies indicated that dose was generally not associated with weight gain; drugs included haloperidol, olanzapine and risperidone,^99^ risperidone,^132^ and risperidone, aripiprazole, olanzapine, and quetiapine.^183^ Doses greater than >1.5 mg/day of risperidone were associated with greater increases in weight (p < 0.0001), waist (p < 0.001), fat mass (p < 0.05) and BMI z-score (p < 0.05).^183^ Three studies reported no influence of stimulant use on weight gain for patients taking SGAs.^149, 151, 158, 183^ Two studies reported that naïve versus previous users of antipsychotics (haloperidol, olanzapine, or risperidone,^99^ and risperidone^158^) did not gain weight of a different magnitude. One study reported that patients who took multiple antipsychotic medications had a greater chance of obesity/excessive weight gain (p < 0.0001) compared to those taking one SGA.^196^

Fasting glucose and development of diabetes. Risperidone, olanzapine, and quetiapine were assocated with a significantly greater increase in serum glucose in children below the age of 12 compared with older children (p < 0.0001).^181^ Olanzapine in doses of >10 mg/day led to significantly higher levels of glucose than did lower doses (p < 0.05).^183^ Stimulant medication use did not significantly influence glucose levels in first-time users of SGAs.^183^ A large retrospective cohort study found that patients ages 13 and over (p < 0.00001), females (p < 0.00001), and those taking more than one antipsychotic (p < 0.001) had a higher likelihood of developing type 2 diabetes when using SGAs.^196^ Higher cumulative doses (< 5g vs. 5–99g vs. ≥100g) of risperidone and any SGA increased the risk for type 2 diabetes. (SGAs: HR, 2.89; 95% CI, 1.64 to 5.10, risperidone: HR, 2.20; 95% CI, 1.14 to 4.26).^193^

Prolactin. Ten studies examined whether age, sex, treatment history, and concurrent medication was associated with changes in AEs related to prolactin. Five studies of risperidone^66, 74, 88, 118, 157^ and clozapine^100^ found that prolactin levels (and prolactin-related effects^74^) were higher in females than males. One study reported opposite findings,^151^ and another reported no difference between sexes.^158^ Single studies found that aripiprazole decreased prolactin levels in males more than in females,^117^ and quetiapine led to greater prolactin increases in males than females.^119^ Two studies found no significant differences in prolactin elevations based on sex during treatment with haloperidol and pimozide,^168^ and haloperidol and olanzapine.^100^ Prolactin levels were significantly lower for risperidone naïve patients compared to patients having previous exposure.^158^ Prolactin levels did not significantly differ for patients taking SGAs with or without stimulants.^183^

Somnolence. Six studies examined whether demographic and clinical subgroup variables influenced reports of somnolence. Rates of somnolence were not affected by age or gender in a study of aripiprazole;^73^ low-dose risperidone resulted in higher occurrence of somnolence in children under versus older than 12.^118^ Somnolence was higher in females than males taking SGAs (p < 0.004).^196^ Low and high doses of aripiprazole were associated with a higher risk for somnolence in Black patients.^73^ Risperidone naïve subjects had higher rates of sedation than did previous users.^158^ Patients taking risperidone experienced a dose-dependent increase in somnolence or fatigue.^118^ Taking multiple versus single SGAs increased the likelihood of somnolence/sedation (p < 0.004).^196^ Pooled analysis^149^ of two RCTs^151, 158^ found a numerical trend suggesting less somnolence in patients receiving combined risperidone/stimulant treatment versus treatment with risperidone alone. Patients taking high-dose quetiapine and stimulants had higher rates of sedation compared to other doses and non-stimulant users.^119^

Neuromotor effects. Three studies examined whether EPS symptoms were moderated by gender, polypharmacy, dose, and ethnicity. EPS were higher in females (p < 0.004) than in males, and in patients taking more than one SGA (p < 0.00001).^196^ Pimozide in higher doses caused greater EPS, while haloperidol dose was not associated with incidence of EPS.^168^ Rates of tardive dyskinesia were similar among patients taking SGAs with and without concurent stimulant, antidepressant, and mood-stabilizer use;^201^ African American patients taking SGAs had more tardive dyskinesia than those of European-American descent.^201^ One study found higher rates of dyskinesia, parkinsonism, and tardive dyskinesia, and no difference in akathisia in drug naïve patients compared with non-drug naïve patients taking various SGAs.