# References

1 Olfson M, Crystal S, Huang C, . Trends in antipsychotic drug use by very young, privately insured children. J Am Acad Child Adolesc Psychiatry. 2010 Jan;49(1):13–23. PMID: 20215922.20215922
2 Pathak P, West D, Martin BC, . Evidence-based use of second-generation antipsychotics in a state Medicaid pediatric population, 2001–2005. Psychiatr Serv. 2010 Feb;61(2):123–9. doi: 10.1176/appi.ps.61.2.123. PMID: 20123816.20123816
3 Zito JM, Safer DJ, de Jong-van den Berg LT, . A three-country comparison of psychotropic medication prevalence in youth. Child Adolesc Psychiatry Ment Health. 2008;2(1):26. doi: 10.1186/1753-2000-2-26. PMID: 18817536.18817536
4 Zito JM, Safer DJ, Sai D, . Psychotropic medication patterns among youth in foster care. Pediatrics. 2008 Jan;121(1):e157–63. doi: 10.1542/peds.2007-0212. PMID: 18166534.18166534
5 Olfson M, King M, Schoenbaum M. Treatment of young people with antipsychotic medications in the United States. JAMA Psychiatry. 2015 Sep;72(9):867–74. doi: 10.1001/jamapsychiatry.2015.0500. PMID: 26132724.26132724
6 IMS Institute for Healthcare Informatics. The Use of Medicines in the United States: Review of 2010. IMS Institute for Healthcare Informatics. NJ, USA: 2011.
7 Crystal S, Olfson M, Huang C, . Broadened use of atypical antipsychotics: safety, effectiveness, and policy challenges. Health Aff (Millwood). 2009 Sep–Oct;28(5):w770–81. doi: 10.1377/hlthaff.28.5.w770. PMID: 19622537.19622537
8 Patten SB, Waheed W, Bresee L. A review of pharmacoepidemiologic studies of antipsychotic use in children and adolescents. Can J Psychiatry. 2012 Dec;57(12):717–21. PMID: 23228229.23228229
9 Fraguas D, Correll CU, Merchan-Naranjo J, . Efficacy and safety of second-generation antipsychotics in children and adolescents with psychotic and bipolar spectrum disorders: comprehensive review of prospective head-to-head and placebo-controlled comparisons. Eur Neuropsychopharmacol. 2011 Aug;21(8):621–45. doi: 10.1016/j.euroneuro.2010.07.002. PMID: 20702068.20702068
10 Panagiotopoulos C, Ronsley R, Elbe D, . First do no harm: promoting an evidence-based approach to atypical antipsychotic use in children and adolescents. J Can Acad Child Adolesc Psychiatry. 2010 May;19(2):124–37. PMID: 20467549.20467549
11 Pringsheim T, Lam D, Ching H, . Metabolic and neurological complications of second-generation antipsychotic use in children: a systematic review and meta-analysis of randomized controlled trials. Drug Saf. 2011 Aug 1;34(8):651–68. doi: 10.2165/11592020-000000000-00000. PMID: 21751826.21751826
12 Correll CU, Penzner JB, Parikh UH, . Recognizing and monitoring adverse events of second-generation antipsychotics in children and adolescents. Child Adolesc Psychiatr Clin N Am. 2006 Jan;15(1):177–206. doi: 10.1016/j.chc.2005.08.007. PMID: 16321730.16321730
13 Rettew DC, Greenblatt J, Kamon J, . Antipsychotic medication prescribing in children enrolled in Medicaid. Pediatrics. 2015 Apr;135(4):658–65. doi: 10.1542/peds.2014-2260. PMID: 25733747.25733747
14 Birnbaum ML, Saito E, Gerhard T, . Pharmacoepidemiology of antipsychotic use in youth with ADHD: trends and clinical implications. Curr Psychiatry Rep. 2013 Aug;15(8):382. doi: 10.1007/s11920-013-0382-3. PMID: 23881713.23881713
15 Schmid I, Burcu M, Zito JM. Medicaid prior authorization policies for pediatric use of antipsychotic medications. JAMA. 2015 Mar 3;313(9):966–8. doi: 10.1001/jama.2015.0763. PMID: 25734740.25734740
16 Findling RL, Drury SS, Jensen PS; American Academy of Child and Adolescent Psychiatry. Practice Parameter for the use of Atypical Antipsychotic Medications in Children and Adolescents. 2012. Available at www.aacap.org
17 Gochman P, Miller R, Rapoport JL. Childhood-onset schizophrenia: the challenge of diagnosis. Curr Psychiatry Rep. 2011 Oct;13(5):321–2. doi: 10.1007/s11920-011-0212-4. PMID: 21713647.21713647
18 Remschmidt H, Theisen FM. Schizophrenia and related disorders in children and adolescents. J Neural Transm Suppl 2005(69):121–41. PMID: 16355606.16355606
19 American Psychiatric Association. Diagnostic and Statistical Manual of Mental Disorders, Fifth Edition American Psychiatric Association. Washington, DC: Publishing AP; 2013. doi: 10.1176/appi.books.9780890425596.
20 Leibenluft E, Rich BA. Pediatric bipolar disorder. Annu Rev Clin Psychol. 2008;4:163–87. doi: 10.1146/annurev.clinpsy.4.022007.141216. PMID: 17716034.17716034
21 Fombonne E. Epidemiological Studies of Pervasive Developmental Disorders. In: Volkmar FP, R.; Klin, A.; Cohen, D., ed Handbook of autism and pervasive developmental disorders. Vol. 1. NJ, US: John Wiley & Sons Inc; 2005:42–69.
22 Prevalence of autism spectrum disorders--Autism and Developmental Disabilities Monitoring Network, 14 sites, United States, 2008. MMWR Surveill Summ. 2012 Mar 30;61(3):1–19. PMID: 22456193.22456193
23 Perou R, Bitsko RH, Blumberg SJ, . Mental health surveillance among children--United States, 2005–2011. MMWR Surveill Summ. 2013 May 17;62 Suppl 2:1–35. PMID: 23677130.23677130
24 Baird G, Simonoff E, Pickles A, . Prevalence of disorders of the autism spectrum in a population cohort of children in South Thames: the Special Needs and Autism Project (SNAP). Lancet. 2006 Jul 15;368(9531):210–5. doi: 10.1016/s0140-6736(06)69041-7. PMID: 16844490.16844490
25 Coury DL, Anagnostou E, Manning-Courtney P, . Use of psychotropic medication in children and adolescents with autism spectrum disorders. Pediatrics. 2012 Nov;130 Suppl 2:S69–76. doi: 10.1542/peds.2012-0900D. PMID: 23118256.23118256
26 Visser SN, Danielson ML, Bitsko RH, . Trends in the parent-report of health care provider-diagnosed and medicated attention-deficit/hyperactivity disorder: United States, 2003–2011. J Am Acad Child Adolesc Psychiatry. 2014 Jan;53(1):34–46 e2. doi: 10.1016/j.jaac.2013.09.001. PMID: 24342384.24342384
27 Costello EJ, Foley DL, Angold A. 10-year research update review: the epidemiology of child and adolescent psychiatric disorders: II. Developmental epidemiology. J Am Acad Child Adolesc Psychiatry. 2006 Jan;45(1):8–25. doi: 10.1097/01.chi.0000184929.41423.c0. PMID: 16327577.16327577
28 Ruscio AM, Stein DJ, Chiu WT, . The epidemiology of obsessive-compulsive disorder in the National Comorbidity Survey Replication. Mol Psychiatry. 2010 Jan;15(1):53–63. doi: 10.1038/mp.2008.94. PMID: 18725912.18725912
29 Diniz JB, Shavitt RG, Fossaluza V, . A double-blind, randomized, controlled trial of fluoxetine plus quetiapine or clomipramine versus fluoxetine plus placebo for obsessive-compulsive disorder. J Clin Psychopharmacol. 2011 Dec;31(6):763–8. doi: 10.1097/JCP.0b013e3182367aee. PMID: 22020357.22020357
30 Kishi T, Matsuda Y, Iwata N, . Antipsychotics for cocaine or psychostimulant dependence: systematic review and meta-analysis of randomized, placebo-controlled trials. J Clin Psychiatry. 2013 Dec;74(12):e1169–80. doi: 10.4088/JCP.13r08525. PMID: 24434105.24434105
31 Vergne DE, Anton RF. Aripiprazole: a drug with a novel mechanism of action and possible efficacy for alcohol dependence. CNS Neurol Disord Drug Targets. 2010 Mar;9(1):50–4. doi: 10.2174/187152710790966731. PMID: 20201815.20201815
32 Nelson JC, Mankoski R, Baker RA, . Effects of aripiprazole adjunctive to standard antidepressant treatment on the core symptoms of depression: a post-hoc, pooled analysis of two large, placebo-controlled studies. J Affect Disord. 2010 Jan;120(1–3):133–40. doi: 10.1016/j.jad.2009.06.026. PMID: 19656577.19656577
33 Chen YC, Chen CK, Wang LJ. Quetiapine fumarate augmentation for patients with a primary anxiety disorder or a mood disorder: a pilot study. BMC Psychiatry. 2012;12:162. doi: 10.1186/1471-244x-12-162. PMID: 23020711.23020711
34 Cohen JA, Bukstein O, Walter H, . Practice parameter for the assessment and treatment of children and adolescents with posttraumatic stress disorder. J Am Acad Child Adolesc Psychiatry. 2010 Apr;49(4):414–30. PMID: 20410735.20410735
35 Gillberg CH, R.; Steinhausen, H. A Clinician’s Handbook of Child and Adolescent Psychiatry. Cambridge: Cambridge University Press; 2006. PMC2247446.
36 Sareen J, Cox BJ, Goodwin RD, . Co-occurrence of posttraumatic stress disorder with positive psychotic symptoms in a nationally representative sample. J Trauma Stress. 2005 Aug;18(4):313–22. doi: 10.1002/jts.20040. PMID: 16281228.16281228
37 Kessler RC, Berglund P, Demler O, . Lifetime prevalence and age-of-onset distributions of DSM-IV disorders in the National Comorbidity Survey Replication. Arch Gen Psychiatry. 2005 Jun;62(6):593–602. doi: 10.1001/archpsyc.62.6.593. PMID: 15939837.15939837
38 Kilpatrick DG, Ruggiero KJ, Acierno R, . Violence and risk of PTSD, major depression, substance abuse/dependence, and comorbidity: results from the National Survey of Adolescents. J Consult Clin Psychol. 2003 Aug;71(4):692–700. doi: 10.1037/0022006X.71.4.692. PMID: 12924674.12924674
39 Han C, Pae CU, Wang SM, . The potential role of atypical antipsychotics for the treatment of posttraumatic stress disorder. J Psychiatr Res. 2014 Sep;56:72–81. doi: 10.1016/j.jpsychires.2014.05.003. PMID: 24882700.24882700
40 Krystal JH, Rosenheck RA, Cramer JA, . Adjunctive risperidone treatment for antidepressant-resistant symptoms of chronic military service-related PTSD: a randomized trial. JAMA. 2011 Aug 3;306(5):493–502. doi: 10.1001/jama.2011.1080. PMID: 21813427.21813427
41 Moore JK, Watson HJ, Harper E, . Psychotropic drug prescribing in an Australian specialist child and adolescent eating disorder service: a retrospective study. J Eat Disord. 2013;1:27. doi: 10.1186/2050-2974-1-27. PMID: 24999406.24999406
42 Cavanna AE, Servo S, Monaco F, . The behavioral spectrum of Gilles de la Tourette syndrome. J Neuropsychiatry Clin Neurosci. 2009 Winter;21(1):13–23. doi: 10.1176/appi.neuropsych.21.1.13. PMID: 19359447.19359447
43 Seida JC, Schouten JR, Mousavi SS, . First- and Second-Generation Antipsychotics for Children and Young Adults. Rockville MD; 2012. PMID: 2243915622439156.
44 Kondo K, O’Neil, M, Mathis, S, McKenna, R, Vander Ley, K, Anderson, J, Helfand, M. Surveilllance Report: First and second generation antipsychotics for children and young adults. Rockville, MD: Agency of Healthcare Research and Quality; 2014.
45 Agency for Healthcare Research and Quality. Methods Guide for Effectiveness and Comparative Effectiveness Reviews. AHRQ Publication No. 10(14)-EHC063-EF. Rockville, MD: AHRQ; 2014.
46 First and Second Generation Antipsychotics for Children and Young Adults-Comparative Effectiveness Review Update Protocol. Agency of Healthcare Research and Quality. 2015. https://effectivehealthcare.ahrq.gov/search-for-guides-reviews-and-reports/?pageaction=displayproduct&productid=2149
47 Higgin JP, Green, S. Section 6.4.11.1 Search filters The Cochrane Handbook for Systematic Reviews of Interventions The Cochrane Collaboration 2011.
48 Higgins JP, Green, S. Section 8. Assessing the risk of bias of included studies Cochrane Handbook for Systematic Reviews of Interventions: The Cochrane Collaroration; 2011.
49 Berkman ND, Lohr KN, Ansari M, . Grading the Strength of a Body of Evidence When Assessing Health Care Interventions for the Effective Health Care Program of the Agency for Healthcare Research and Quality: An Update Methods Guide for Effectiveness and Comparative Effectiveness Reviews. Rockville MD; 2008.
50 Wells G, Shea, B, O’Connell, N, Peterson, J, Welch, V, Losos, M, Tugwell, P. The Newcastle-Ottawa Scale for Assessing the Quality of Nonrandomized Studies in Meta-analyses. Ottawa, ON: Department of Epidemiology and Community Medicine, University of Ottawa 2009.
51 Lu G, Ades AE. Combination of direct and indirect evidence in mixed treatment comparisons. Stat Med. 2004 Oct 30;23(20):3105–24. doi: 10.1002/sim.1875. PMID: 15449338.15449338
52 Lumley T. Network meta-analysis for indirect treatment comparisons. Stat Med. 2002 Aug 30;21(16):2313–24. doi: 10.1002/sim.1201. PMID: 12210616.12210616
53 Sutton AJ, Abrams KR. Bayesian methods in meta-analysis and evidence synthesis. Stat Methods Med Res. 2001 Aug;10(4):277–303. doi: 10.1177/096228010101000404. PMID: 1149141.11491414
54 Cornell JE, Mulrow CD, Localio R, . Random-effects meta-analysis of inconsistent effects: a time for change. Ann Intern Med. 2014 Feb 18;160(4). PMID: 24727843.24727843
55 Golder S, Loke YK, Bland M. Meta-analysis of adverse effects data derived from randomised controlled trials as compared to observational studies: methodological overview. PLoS Med. 2011;8(5): e1001026. doi: 10.1371/journal.pmed.1001026. PMID: 21559325.21559325
56 Egger M, Davey Smith G, Schneider M, . Bias in meta-analysis detected by a simple, graphical test. BMJ. 1997 Sep 13;315(7109):629–34. doi: 10.1136/bmj.315.7109.629. PMID: 9310563.9310563
57 Veroniki AA, Mavridis D, Higgins J, Salanti G. Characteristics of a loop of evidence that affect detection and estimation of inconsistency: a simulation study BMC Medical Research Methodology. 2014;14:106.25239546
58 Achana FA, Cooper NJ, Bujkiewicz S, . Network meta-analysis of multiple outcome measures accounting for borrowing of information across outcomes. BMC Med Res Methodol. 2014;14:92. doi: 10.1186/1471-2288-14-92. PMID: 25047164.25047164
59 Keevil VL, Khaw KT. Overadjustment in regression analyses: considerations when evaluating relationships between body mass index, muscle strength, and body size. J Gerontol A Biol Sci Med Sci. 2014 May;69(5):616–7. doi: 10.1093/gerona/glt186. PMID: 24300030.24300030
60 Guyatt GH, Oxman AD, Kunz R, . GRADE guidelines 6. Rating the quality of evidence--imprecision. J Clin Epidemiol. 2011 Dec;64(12):1283–93. doi: 10.1016/j.jclinepi.2011.01.012. PMID: 21839614.21839614
61 Glenton C, Santesso N, Rosenbaum S, . Presenting the results of Cochrane systematic reviews to a consumer audience: a qualitative study. Med Decis Making. 2010; 30:566–577. doi: 10.1177/0272989X10375853. PMID: 2064391220643912
62 Biederman J, Mick E. Comparative open-label trial of atypical neuroleptics in children and adolescents with bipolar disorder. Eur Neuropsychopharmacol. 2004;14(suppI3):S211–S2. doi: 10.1016/S0924-977X(04)80177-9.
63 Jefferson AM, Markowitz JS, Brewerton TD. Atypical antipsychotics. J Am Acad Child Adolesc Psychiatry 1998;Vol.37(12):1243–4. doi: 10.1097/00004583-199812000-00004. PMID: 9847493.9847493
64 Schulz E, Fleischhaker C, Remschmidt HE. Correlated changes in symptoms and neurotransmitter indices during maintenance treatment with clozapine or conventional neuroleptics in adolescents and young adults with schizophrenia. J Child Adolesc Psychopharmacol. 1996;6(2):119–31. doi: 10.1089/cap.1996.6.119. PMID: 9231304.9231304
65 DelBello MP, Versavel M, Ice K, . Tolerability of oral ziprasidone in children and adolescents with bipolar mania, schizophrenia, or schizoaffective disorder. J Child Adolesc Psychopharmacol. 2008;18(5):491–9. doi: 10.1089/cap.2008.008. PMID: 18928413.18928413
66 Conus P, Berk M, Cotton SM, . Olanzapine or chlorpromazine plus lithium in first episode psychotic mania: An 8-week randomised controlled trial. European Psychiatry. 2015;30:975–82.26485297
67 Arango C, Robles O, Parellada M, . Olanzapine compared to quetiapine in adolescents with a first psychotic episode. Eur Child Adolesc Psychiatry. 2009;18(7):418–28. doi: 10.1007/s00787-009-0749-5. PMID: 19198920.19198920
68 Berger GE, Proffitt TM, McConchie M, . Dosing quetiapine in drug-naive first-episode psychosis: a controlled, double-blind, randomized, single-center study investigating efficacy, tolerability, and safety of 200 mg/day vs. 400 mg/day of quetiapine fumarate in 141 patients aged 15 to 25 years. J Clin Psychiatry. 2008;69(11):1702–14. PMID: 19036233.19036233
69 Crocq MA, Guillon MS, Bailey PE, . Orally disintegrating olanzapine induces less weight gain in adolescents than standard oral tablets. Eur Psychiatry. 2007;22(7):453–4. doi:10.1016/j.eurpsy.2007.06.004. PMID: 17761403.17761403
70 deHaan L, van Bruggen M, Lavalaye J, . Subjective experience and D2 receptor occupancy in patients with recent-onset schizophrenia treated with low-dose olanzapine or haloperidol: a randomized, double-blind study. Am J Psychiatry. 2003;160(2):303–9. doi: 10.1176/appi.ajp.160.2.303. PMID: 12562577.12562577
71 Findling RL, Cavus I, Pappadopulos E, . Ziprasidone in adolescents with schizophrenia: results from a placebo-controlled efficacy and long-term open-extension study. J Child Adolesc Psychopharmacol. 2013a Oct;23(8):531–44. doi: 10.1089/cap.2012.0068. PMID: 24111983.24111983
72 Findling RL, McKenna K, Earley WR, . Efficacy and safety of quetiapine in adolescents with schizophrenia investigated in a 6-week, double-blind, placebo-controlled trial. J Child Adolesc Psychopharmacol. 2012a Oct;22(5):327–42. doi: 10.1089/cap.2011.0092. PMID: 23083020.23083020
73 Findling RL, Robb A, Nyilas M, . A multiple-center, randomized, double-blind, placebo-controlled study of oral aripiprazole for treatment of adolescents with schizophrenia. Am J Psychiatry. 2008a;165(11):1432–41. doi: 10.1176/appi.ajp.2008.07061035. PMID: 18765484.18765484
74 Haas M, Eerdekens M, Kushner S, . Efficacy, safety and tolerability of two dosing regimens in adolescent schizophrenia: double-blind study. Br J Psychiatry. 2009a;194(2):158–64. doi: 10.1192/bjp.bp.107.046177. PMID: 19182179.19182179
75 Jensen JB, Kumra S, Leitten W, . A comparative pilot study of second-generation antipsychotics in children and adolescents with schizophrenia-spectrum disorders. J Child Adolesc Psychopharmacol. 2008;18(4):317–26. doi: 10.1089/cap.2007.0123. PMID: 18759641.18759641
76 Kryzhanovskaya L, Schulz SC, McDougle C, . Olanzapine versus placebo in adolescents with schizophrenia: a 6-week, randomized, double-blind, placebo-controlled trial. J Am Acad Child Adolesc Psychiatry. 2009;48(1):60–70. doi: 10.1097/CHI.0b013e3181900404. PMID: 19057413.19057413
77 Kumra S, Frazier JA, Jacobsen LK, . Childhood-onset schizophrenia. A double-blind clozapine-haloperidol comparison. Arch Gen Psychiatry. 1996;53(12):1090–7. doi:10.1001/archpsyc.1996.01830120020005. PMID: 8956674.8956674
78 Kumra S, Kranzler H, Gerbino-Rosen G, . Clozapine and “high-dose” olanzapine in refractory early-onset schizophrenia: a 12-week randomized and double-blind comparison. Biol Psychiatry. 2008;63(5):524–9. doi:10.1016/j.biopsych.2007.04.043. PMID: 17651705.17651705
79 Mozes T, Ebert T, Michal SE, . An open-label randomized comparison of olanzapine versus risperidone in the treatment of childhood-onset schizophrenia. J Child Adolesc Psychopharmacol. 2006;16(4):393–403. doi:10.1089/cap.2006.16.393. PMID: 16958565.16958565
80 Shaw P, Sporn A, Gogtay N, . Childhood-onset schizophrenia: A double-blind, randomized clozapine-olanzapine comparison. Arch Gen Psychiatry. 2006;63(7):721–30. doi:10.1001/archpsyc.63.7.721. PMID: 16818861.16818861
81 Sikich L, Frazier JA, McClellan J, . Double-blind comparison of first- and second-generation antipsychotics in early-onset schizophrenia and schizo-affective disorder: findings from the treatment of early-onset schizophrenia spectrum disorders (TEOSS) study. Am J Psychiatry. 2008;165(11):1420–31. doi: 10.1176/appi.ajp.2008.08050756. PMID: 18794207.18794207
82 Sikich L, Hamer RM, Bashford RA, . A pilot study of risperidone, olanzapine, and haloperidol in psychotic youth: a double-blind, randomized, 8-week trial. Neuropsychopharmacology. 2004;29(1):133–45. doi:10.1038/sj.npp.1300327 PMID: 14583740.14583740
83 Spencer EK, Campbell M. Children with schizophrenia: diagnosis, phenomenology, and pharmacotherapy. Schizophr Bull. 1994;20(4):713–25. doi: 10.1093/schbul/20.4.713. PMID: 7701278.7701278
84 Swadi HS, Craig BJ, Pirwani NZ, . A trial of quetiapine compared with risperidone in the treatment of first onset psychosis among 15-to 18-year-old adolescents. Int Clin Psychopharmacol. 2010;25(1):1–6. doi: 10.1097/YIC.0b013e3283320511. PMID: 19809337.19809337
85 van Bruggen J, Tijssen J, Dingemans P, . Symptom response and side-effects of olanzapine and risperidone in young adults with recent onset schizophrenia. Int Clin Psychopharmacol. 2003;18(6):341–6. PMID: 14571154.14571154
86 Woods SW, Breier A, Zipursky RB, . Randomized trial of olanzapine versus placebo in the symptomatic acute treatment of the schizophrenic prodrome. Biol Psychiatry. 2003;54(4):453–64. doi:10.1016/S0006-3223(03)00321-4. PMID: 12915290.12915290
87 Yen YC, Lung F-W, Chong MY. Adverse effects of risperidone and haloperidol treatment in schizophrenia. Prog Neuropsychopharmacol Biol Psychiatry 2004;Vol.28(2):285–90. doi: 10.1016/j.pnpbp.2003.10.006. PMID: 14751424.14751424
88 Haas M, Unis AS, Armenteros J, . A 6-week, randomized, double-blind, placebo-controlled study of the efficacy and safety of risperidone in adolescents with schizophrenia. J Child Adolesc Psychopharmacol. 2009b;19(6):611–21. doi: 10.1089/cap.2008.0144. PMID: 20035579.20035579
89 Johnson & Johnson Pharmaceutical Research & Development. Open-label study to evaluate the safety and pharmacokinetics of single- and multiple-dose extended-release paliperidone in pediatric subjects (10 to 17 years of age) with schizophrenia, schizoaffective disorder, or schizophreniform disorder. (Clinical Study Report). 2011.
90 Singh J, Robb A, Vijapurkar U, . A randomized, double-blind study of paliperidone extended-release in treatment of acute schizophrenia in adolescents. Biol Psychiatry. 2011 Dec 15;70(12):1179–87. doi: 10.1016/j.biopsych.2011.06.021. PMID: 21831359.21831359
91 Buchsbaum MS, Haznedar MM, Aronowitz J, . FDG-PET in never-previously medicated psychotic adolescents treated with olanzapine or haloperidol. Schizophr Res. 2007 Aug;94(1–3):293–305. doi:10.1016/j.schres.2007.04.027. PMID: 17574821.17574821
92 Findling RL, Landbloom RP, Mackle M, . Safety and Efficacy from an 8 Week Double-Blind Trial and a 26 Week Open-Label Extension of Asenapine in Adolescents with Schizophrenia. J Child Adolesc Psychopharmacol. 2015a Jun;25(5):384–96. doi: http://dx.doi.org/10.1089/cap.2015.0027. PMID: 26091193.26091193
93 McGorry PD, Nelson B, Phillips LJ, . Randomized controlled trial of interventions for young people at ultra-high risk of psychosis: twelve-month outcome. J Clin Psychiatry. 2013 Apr;74(4):349–56. doi: http://dx.doi.org/10.4088/JCP.12m07785. PMID: 23218022.23218022
94 Savitz AJ, Lane R, Nuamah I, . Efficacy and safety of paliperidone extended release in adolescents with schizophrenia: a randomized, double-blind study. J Am Acad Child Adolesc Psychiatry. 2015 Feb;54(2):126–37.e1. doi: http://dx.doi.org/10.1016/j.jaac.2014.11.009. PMID: 25617253.25617253
95 NCT01149655. Efficacy & Safety Study of Oral Aripiprazole in Adolescents With Schizophrenia. 2015. Available at https://clinicaltrials.gov/ct2/show/NCT01149655?term=NCT01149655&rank=1
96 Gothelf D, Falk B, Singer P, . Weight gain associated with increased food intake and low habitual activity levels in male adolescent schizophrenic inpatients treated with olanzapine. Am J Psychiatry. 2002;159(6):1055–7. doi: 10.1176/appi.ajp.159.6.1055 PMID: 12042200.12042200
97 Hrdlicka M, Zedkova I, Blatny M, . Weight gain associated with atypical and typical antipsychotics during treatment of adolescent schizophrenic psychoses: A retrospective study. Neuroendocrinology Lett. 2009;30(2):256–61. PMID: 19675512.19675512
98 Kumra S, Jacobsen LK, Lenane M, . Childhood-onset schizophrenia: an open-label study of olanzapine in adolescents. J Am Acad Child Adolesc Psychiatry. 1998;37(4):377–85. doi:10.1097/00004583-199804000-00015. PMID: 9549958.9549958
99 Ratzoni G, Gothelf D, Brand-Gothelf A, . Weight Gain Associated with Olanzapine and Risperidone in Adolescent Patients: A Comparative Prospective Study. J Am Acad Child Adolesc Psychiatry. 2002;41(3):337–43. doi:10.1097/00004583-200203000-00014 PMID: 11886029.11886029
100 Wudarsky M, Nicolson R, Hamburger SD, . Elevated prolactin in pediatric patients on typical and atypical antipsychotics. Journal of Child and Adolescent Psychopharmacology 9.(4)(pp 239–245), 1999. Date of Publication: 1999. 1999(4):239–45.10630453
101 Castro-Fornieles J, Parellada M, Soutullo CA, . Antipsychotic treatment in child and adolescent first-episode psychosis: a longitudinal naturalistic approach. J Child Adolesc Psychopharmacol. 2008 Aug;18(4):327–36. doi: http://dx.doi.org/10.1089/cap.2007.0138. PMID: 18759642.18759642
102 Cianchetti C, Ledda MG. Effectiveness and safety of antipsychotics in early onset psychoses: a long-term comparison. Psychiatry Res. 2011 Oct 30;189(3):349–56. doi: http://dx.doi.org/10.1016/j.psychres.2011.03.020. PMID: 21570128.21570128
103 O’Donoghue B, Schafer MR, Becker J, . Metabolic changes in first-episode early-onset schizophrenia with second-generation antipsychotics. Early Interv Psychiatry. 2014 Aug;8(3):276–80. doi: http://dx.doi.org/10.1111/eip.12083. PMID: 23968390.23968390
104 Olfson M, Gerhard T, Huang C, . Comparative effectiveness of second-generation antipsychotic medications in early-onset schizophrenia. Schizophr Bull. 2012 Jun;38(4):845–53. doi: http://dx.doi.org/10.1093/schbul/sbq172. PMID: 21307041.21307041
105 Schneider MR, Adler CM, Whitsel R, . The effects of ziprasidone on prefrontal and amygdalar activation in manic youth with bipolar disorder. Isr J Psychiatry Relat Sci. 2012;49(2):112–20. PMID: 22801290.22801290
106 NCT00194012. Study of Aripiprazole (Abilify) Versus Placebo in Children With Subsyndromal Bipolar Disorder. 2014. Available at https://clinicaltrials.gov/ct2/show/NCT00194012?term=NCT00194012&rank=1
107 Oh J, Chang JG, Lee SB, . Comparison of aripiprazole and other atypical antipsychotics for pediatric bipolar disorder: a retrospective chart review of efficacy and tolerability. Clin Psychopharmacol Neurosci. 2013 Aug;11(2):72–9. doi: http://dx.doi.org/10.9758/cpn.2013.11.2.72. PMID: 24023551.24023551
108 Findling RL, Landbloom RL, Szegedi A, . Asenapine for the Acute Treatment of Pediatric Manic or Mixed Episode of Bipolar I Disorder. J Am Acad Child Adolesc Psychiatry. 2015b Dec;54(12):1032–41. doi: 10.1016/j.jaac.2015.09.007. PMID: 26598478.26598478
109 Findling RL, Pathak S, Earley WR, . Efficacy and safety of extended-release quetiapine fumarate in youth with bipolar depression: an 8 week, double-blind, placebo-controlled trial. J Child Adoles Psychopharmacol. 2014a Aug;24(6):325–35. doi: http://dx.doi.org/10.1089/cap.2013.0105. PMID: 24956042.24956042
110 Findling RL, Youngstrom EA, McNamara NK, . Double-blind, randomized, placebo-controlled long-term maintenance study of aripiprazole in children with bipolar disorder. J Clin Psychiatry. 2012b Jan;73(1):57–63. doi: http://dx.doi.org/10.4088/JCP.11m07104. PMID: 22152402.22152402
111 Kowatch RA, Scheffer RE, Monroe E, . Placebo-controlled trial of valproic Acid versus risperidone in children 3–7 years of age with bipolar I disorder. J Child Adoles Psychopharmacol. 2015 May;25(4):306–13. doi: http://dx.doi.org/10.1089/cap.2014.0166. PMID: 25978742.25978742
112 Masi G, Milone A, Stawinoga A, . Efficacy and Safety of Risperidone and Quetiapine in Adolescents With Bipolar II Disorder Comorbid With Conduct Disorder. J Clin Psychopharmacol. 2015 Oct;35(5):587–90. doi: http://dx.doi.org/10.1097/JCP.0000000000000371. PMID: 26226481.26226481
113 Biederman J, Mick E, Hammerness P, . Open-label, 8-week trial of olanzapine and risperidone for the treatment of bipolar disorder in preschool-age children. Biol Psychiatry. 2005; 58(7):589–94. doi:10.1016/j.biopsych.2005.03.019. PMID: 16239162.16239162
114 DelBello MP, Chang K, Welge JA, . A double-blind, placebo-controlled pilot study of quetiapine for depressed adolescents with bipolar disorder. Bipolar Disord. 2009;11(5):483–93. doi: 10.1111/j.1399-5618.2009.00728.x. PMID: 19624387.19624387
115 DelBello MP, Schwiers ML, Rosenberg HL, . A double-blind, randomized, placebo-controlled study of quetiapine as adjunctive treatment for adolescent mania. J Am Acad Child Adoles Psychiatry. 2002;41(10):1216–23. doi:10.1097/00004583-200210000-00011 PMID: 12364843.12364843
116 Findling RL, Cavus I, Pappadopulos E, . Efficacy, long-term safety, and tolerability of ziprasidone in children and adolescents with bipolar disorder. J Child Adolesc Psychopharmacol. 2013b Oct;23(8):545–57. doi: 10.1089/cap.2012.0029. PMID: 24111980.24111980
117 Findling RL, Nyilas M, Forbes RA, . Acute treatment of pediatric bipolar I disorder, manic or mixed episode, with aripiprazole: a randomized, double-blind, placebo-controlled study. J Clin Psychiatry. 2009;70(10):1441–51. doi: 10.4088/JCP.09m05164yel. PMID: 19906348.19906348
118 Haas M, Delbello MP, Pandina G, . Risperidone for the treatment of acute mania in children and adolescents with bipolar disorder: a randomized, double-blind, placebo-controlled study. Bipolar Disord. 2009c;11(7):687–700. doi: 10.1111/j.1399-5618.2009.00750.x. PMID: 19839994.19839994
119 Pathak S., Findling RL, Earley WR, . Efficacy and safety of quetiapine in children and adolescents with mania associated with bipolar I disorder: a 3-week, double-blind, placebo-controlled trial. J Clin Psychiatry. 2013 Jan;74(1):e100–9. doi: 10.4088/JCP.11m07424. PMID: 23419231.23419231
120 Tohen M, Kryzhanovskaya L, Carlson G, . Olanzapine versus placebo in the treatment of adolescents with bipolar mania. Am J Psychiatry. 2007;164(10):1547–56. http://dx.doi.org/10.1176/appi.ajp.2007.06111932 PMID: 17898346.17898346
121 Tramontina S, Zeni CP, Ketzer CR, . Aripiprazole in children and adolescents with bipolar disorder comorbid with attention-deficit/hyperactivity disorder: a pilot randomized clinical trial. J Clin Psychiatry. 2009;70(5):756–64. doi: 10.4088/JCP.08m04726. PMID: 19389329.19389329
122 Anderson LT, Campbell M, Adams P, . The effects of haloperidol on discrimination learning and behavioral symptoms in autistic children. J Autism Dev Disord. 1989 Jun;19(2):227–39. PMID: 2663834.2663834
123 Findling RL, Mankoski R, Timko K, . A randomized controlled trial investigating the safety and efficacy of aripiprazole in the long-term maintenance treatment of pediatric patients with irritability associated with autistic disorder. J Clin Psychiatry. 2014b Jan;75(1):22–30. doi: http://dx.doi.org/10.4088/JCP.13m8500. PMID: 24502859.24502859
124 Ghanizadeh A, Sahraeizadeh A, Berk M. A head-to-head comparison of aripiprazole and risperidone for safety and treating autistic disorders, a randomized double blind clinical trial. Child Psychiatry Hum Dev. 2014a;45(2):185–92. doi: http://dx.doi.org/10.1007/s10578-013-0390-x. PMID: 23801256.23801256
125 Hellings JA, Zarcone JR, Reese RM, . A crossover study of risperidone in children, adolescents and adults with mental retardation. J Autism Dev Disord. 2006;36(3):401–11. doi: 10.1007/s10803-006-0078-1 PMID: 16596465.16596465
126 Hollander E, Wasserman S, Swanson EN, . A double-blind placebo-controlled pilot study of olanzapine in childhood/adolescent pervasive developmental disorder. J Child Adolesc Psychopharmacol. 2006;16(5):541–8. doi:10.1089/cap.2006.16.541. PMID: 17069543.17069543
127 Loebel A, Brams M, Goldman RS, . Lurasidone for the treatment of irritability with autistic disorder. J Autism Dev Disord. 2016;46:1153–63.26659550
128 Kent JM, Kushner S, Ning X, . Risperidone dosing in children and adolescents with autistic disorder: a double-blind, placebo-controlled study. J Autism Dev Disord. 2013 Aug;43(8):1773–83. doi: 10.1007/s10803-012-1723-5. PMID: 23212807.23212807
129 Luby J, Mrakotsky C, Stalets MM, . Risperidone in preschool children with autistic spectrum disorders: an investigation of safety and efficacy. J Child Adoles Psychopharmacol. 2006;16(5):575–87. doi:10.1089/cap.2006.16.575. PMID: 17069546.17069546
130 Malone RP, Cater J, Sheikh RM, . Olanzapine versus haloperidol in children with autistic disorder: an open pilot study. J Am Acad Child Adolesc Psychiatry. 2001;40(8):887–94. doi:10.1097/00004583-200108000-00009 PMID: 11501687.11501687
131 Marcus RN, Owen R, Kamen L, . A placebo-controlled, fixed-dose study of aripiprazole in children and adolescents with irritability associated with autistic disorder. J Am Acad Child Adolesc Psychiatry. 2009;48(11):1110–9. doi: 10.1097/CHI.0b013e3181b76658. PMID: 19797985.19797985
132 McCracken JT, McGough J, Shah B, . Risperidone in children with autism and serious behavioral problems. N Engl J Med. 2002;347(5):314–21. doi: 10.1056/NEJMoa013171 PMID: 12151468.12151468
133 Miral S, Gencer O, Inal-Emiroglu FN, . Risperidone versus haloperidol in children and adolescents with AD: a randomized, controlled, double-blind trial. Eur Child Adolesc Psychiatry. 2008;17(1):1–8. PMID: 18080171.18080171
134 Nagaraj R, Singhi P, Malhi P. Risperidone in children with autism: randomized, placebo-controlled, double-blind study. J Child Neurol. 2006;21(6):450–5. doi: 10.1177/08830738060210060801. PMID: 16948927.16948927
135 Owen R, Sikich L, Marcus RN, . Aripiprazole in the treatment of irritability in children and adolescents with autistic disorder. Pediatrics. 2009;124(6):1533–40. doi: 10.1542/peds.2008-3782. PMID: 19948625.19948625
136 Perry R, Campbell M, Adams P, . Long-term efficacy of haloperidol in autistic children: continuous versus discontinuous drug administration. J Am Acad Child Adolesc Psychiatry. 1989;28(1):87–92. doi:10.1097/00004583-198901000-00016 PMID: 2914841.2914841
137 Remington G, Sloman L, Konstantareas M, . Clomipramine versus haloperidol in the treatment of autistic disorder: a double-blind, placebo-controlled, crossover study. J Clin Psychopharmacol. 2001 Aug;21(4):440–4. PMID: 11476129.11476129
138 Research Units on Pediatric Psychopharmacology (RUPP). Risperidone treatment of autistic disorder: longer-term benefits and blinded discontinuation after 6 months. Am J Psychiatry. 2005;162(7):1361–9. http://dx.doi.org/10.1176/appi.ajp.162.7.1361 PMID: 15994720.15994720
139 Shea S, Turgay A, Carroll A, . Risperidone in the treatment of disruptive behavioral symptoms in children with autistic and other pervasive developmental disorders. Pediatrics. 2004;114(5):e634–e41. PMID: 15492353.15492353
140 Troost PW, Lahuis BE, Steenhuis MP, . Long-term effects of risperidone in children with autism spectrum disorders: a placebo discontinuation study. J Am Acad Child Adolesc Psychiatry. 2005;44(11):1137–44. doi:10.1097/01.chi.0000177055.11229.76 PMID: 16239862.16239862
141 NCT00619190. Study of Aripiprazole to Treat Children and Adolescents With Autism. 2014. Available at https://clinicaltrials.gov/ct2/show/NCT00619190?term=00619190&rank=1
142 Mankoski R, Stockton G, Manos G, . Aripiprazole treatment of irritability associated with autistic disorder and the relationship between prior antipsychotic exposure, adverse events, and weight change. J Child Adolesc Psychopharmacol. 2013 Oct;23(8):572–6. doi: http://dx.doi.org/10.1089/cap.2012.0075. PMID: 24138011.24138011
143 Novaes CM, Ponde MP, Freire AC. Control of psychomotor agitation and aggressive behavior in patients with autistic disorder: a retrospective chart review. Arq Neuropsiquiatr. 2008;66(3B):646–51. doi: 10.1590/S0004-282X2008000500008. PMID: 18949256.18949256
144 Wink LK, Early M, Schaefer T, . Body mass index change in autism spectrum disorders: comparison of treatment with risperidone and aripiprazole. J Child Adolesc Psychopharmacol. 2014 Mar;24(2):78–82. doi: http://dx.doi.org/10.1089/cap.2013.0099. PMID: 24564519.24564519
145 Troost PW, Althaus M, Lahuis BE, . Neuropsychological effects of risperidone in children with pervasive developmental disorders: a blinded discontinuation study. J Child Adolesc Psychopharmacol. 2006;16(5):561–73. doi:10.1089/cap.2006.16.561. PMID: 17069545.17069545
146 Pandina GJ, Bilder R, Harvey PD, . Risperidone and cognitive function in children with disruptive behavior disorders. Biol Psychiatry. 2007 Aug 1;62(3):226–34. doi:10.1016/j.biopsych.2006.09.036. PMID: 17210137.17210137
147 Aman MG, Bukstein OG, Gadow KD, . What does risperidone add to parent training and stimulant for severe aggression in child attention-deficit/hyperactivity disorder? J Am Acad Child Adolesc Psychiatry. 2014 Jan;53(1):47–60.e1. doi: http://dx.doi.org/10.1016/j.jaac.2013.09.022. PMID: 24342385.24342385
148 Stocks JD, Taneja BK, Baroldi P, . A phase 2a randomized, parallel group, dose-ranging study of molindone in children with attention-deficit/hyperactivity disorder and persistent, serious conduct problems. J Child Adolesc Psychopharmacol. 2012 Apr;22(2):102–11. doi: http://dx.doi.org/10.1089/cap.2011.0087. PMID: 22372512.22372512
149 Aman MG, Binder C, Turgay A. Risperidone effects in the presence/absence of psychostimulant medicine in children with ADHD, other disruptive behavior disorders, and subaverage IQ. J Child Adolesc Psychopharmacol. 2004;14(2):243–54. doi:10.1089/1044546041649020. PMID: 15319021.15319021
150 Aman MG, Marks RE, Turbott SH, . Clinical effects of methylphenidate and thioridazine in intellectually subaverage children. J Am Acad Child Adolesc Psychiatry. 1991 Mar;30(2):246–56. doi:10.1097/00004583-199103000-00013 PMID: 2016229.2016229
151 Aman MG, De SG, Derivan A, . Double-blind, placebo-controlled study of risperidone for the treatment of disruptive behaviors in children with subaverage intelligence. Am J Psychiatry. 2002;159(8):1337–46. http://dx.doi.org/10.1176/appi.ajp.159.8.1337 PMID: 12153826.12153826
152 Aman MG, Hollway JA, Leone S, . Effects of risperidone on cognitive-motor performance and motor movements in chronically medicated children. Res Dev Disabil. 2009;30(2):386–96. doi: 10.1016/j.ridd.2008.07.004. PMID: 18768293.18768293
153 Armenteros Jl, Lewis JE, Davalos M. Risperidone augmentation for treatment-resistant aggression in attention-deficit/hyperactivity disorder: a placebo-controlled pilot study. J Am Acad Child Adolesc Psychiatry 2007(5):558–65. doi:10.1097/chi.0b013e3180323354 PMID: 17450046.17450046
154 Buitelaar JK, van der Gaag RJ, Cohen-Kettenis P, . A randomized controlled trial of risperidone in the treatment of aggression in hospitalized adolescents with subaverage cognitive abilities. J Clin Psychiatry. 2001;62(4):239–48. PMID: 11379837.11379837
155 Connor DF, McLaughlin TJ, Jeffers-Terry M. Randomized controlled pilot study of quetiapine in the treatment of adolescent conduct disorder. J Child Adolesc Psychopharmacol. 2008;18(2):140–56. doi: 10.1089/cap.2006.0007. PMID: 18439112.18439112
156 Findling RL, McNamara NK, Branicky LA, . A double-blind pilot study of risperidone in the treatment of conduct disorder. J Am Acad Child Adolesc Psychiatry. 2000;39(4):509–16. doi:10.1097/00004583-200004000-00021 PMID: 10761354.10761354
157 Reyes M, Buitelaar J, Toren P, . A randomized, double-blind, placebo-controlled study of risperidone maintenance treatment in children and adolescents with disruptive behavior disorders. Am J Psychiatry. 2006;163(3):402–10. http://dx.doi.org/10.1176/appi.ajp.163.3.402 PMID: 16513860.16513860
158 Snyder R, Turgay A, Aman M, . Effects of risperidone on conduct and disruptive behavior disorders in children with subaverage IQs. J Am Acad Child Adolesc Psychiatry. 2002;41(9):1026–36. PMID: 12218423.12218423
159 Masi G, Pfanner C, Brovedani P. Antipsychotic augmentation of selective serotonin reuptake inhibitors in resistant tic-related obsessive-compulsive disorder in children and adolescents: a naturalistic comparative study. J Psychiatr Res. 2013 Aug;47(8):1007–12. doi: http://dx.doi.org/10.1016/j.jpsychires.2013.04.003. PMID: 23664673.23664673
160 Weisler RH, Khan A, Trivedi MH, . Analysis of suicidality in pooled data from 2 double-blind, placebo-controlled aripiprazole adjunctive therapy trials in major depressive disorder. J Clin Psychiatry. 2011 Apr;72(4):548–55. doi: http://dx.doi.org/10.4088/JCP.09m05495gre. PMID: 20816039.20816039
161 Hagman J, Gralla J, Sigel E, . A double-blind, placebo-controlled study of risperidone for the treatment of adolescents and young adults with anorexia nervosa: a pilot study. J Am Acad Child Adolesc Psychiatry. 2011 Sep;50(9):915–24. doi: http://dx.doi.org/10.1016/j.jaac.2011.06.009. PMID: 21871373.21871373
162 Kafantaris V, Leigh E, Hertz S, . A placebo-controlled pilot study of adjunctive olanzapine for adolescents with anorexia nervosa. J Child Adolesc Psychopharmacol. 2011 Jun;21(3):207–12. doi: http://dx.doi.org/10.1089/cap.2010.0139. PMID: 21663423.21663423
163 Norris ML, Spettigue W, Buchholz A, . Olanzapine use for the adjunctive treatment of adolescents with anorexia nervosa. J Child Adolesc Psychopharmacol. 2011 Jun;21(3):213–20. doi: http://dx.doi.org/10.1089/cap.2010.0131. PMID: 21510781.21510781
164 Bruggeman R, van der LC, Buitelaar JK, . Risperidone versus pimozide in Tourette’s disorder: a comparative double-blind parallel-group study. J Clin Psychiatry. 2001;62(1):50–6. PMID: 16239162.16239162
165 Ghanizadeh A, Haghighi A. Aripiprazole versus risperidone for treating children and adolescents with tic disorder: a randomized double blind clinical trial. Child Psychiatry Hum Dev 2014b 01 Oct;45(5):596–603. doi:http://dx.doi.org/10.1007/s10578-013-0427-1. PMID: 24343476.24343476
166 Gilbert DL, Batterson JR, Sethuraman G, . Tic reduction with risperidone versus pimozide in a randomized, double-blind, crossover trial. J Am Acad Child Adolesc Psychiatry 2004;Vol.43(2):206–14. doi:10.1097/00004583-200402000-00017. PMID: 14726728.14726728
167 Sallee FR, Kurlan R, Goetz CG, . Ziprasidone treatment of children and adolescents with Tourette’s syndrome: a pilot study. J Am Acad Child Adolesc Psychiatry. 2000;39(3):292–9. doi:10.1097/00004583-200003000-00010. PMID: 10714048.10714048
168 Sallee FR, Nesbitt L, Jackson C, . Relative efficacy of haloperidol and pimozide in children and adolescents with Tourette’s disorder. Am J Psychiatry. 1997;154(8):1057–62. http://dx.doi.org/10.1176/ajp.154.8.1057 PMID: 9247389.9247389
169 Sallee FR, Sethuraman G, Rock CM. Effects of pimozide on cognition in children with Tourette syndrome: interaction with comorbid attention deficit hyperactivity disorder. Acta Psychiatr Scand. 1994;90(1):4–9. doi: 10.1111/j.1600-0447.1994.tb01546.x PMID: 7976448.7976448
170 Scahill L, Leckman JF, Schultz RT, . A placebo-controlled trial of risperidone in Tourette syndrome. Neurology. 2003;60(7):1130–5. PMID: 12682319.12682319
171 Sehgal N. Short-term versus longer term pimozide therapy in Tourette’s syndrome: a preliminary study. Neurology. 1999;52(4):874–7. PMID: 10078748.10078748
172 Yoo HK, Joung YS, Lee JS, . A multicenter, randomized, double-blind, placebo-controlled study of aripiprazole in children and adolescents with Tourette’s disorder. J Clin Psychiatry. 2013 Aug;74(8):e772–80. doi: http://dx.doi.org/10.4088/JCP.12m08189. PMID: 24021518.24021518
173 Gulisano M, Cali PV, Cavanna AE, . Cardiovascular safety of aripiprazole and pimozide in young patients with Tourette syndrome. Neurol Sci. 2011 Dec;32(6):1213–7. doi: http://dx.doi.org/10.1007/s10072-011-0678-1. PMID: 21732066.21732066
174 Rizzo R, Eddy CM, Cali P, . Metabolic effects of aripiprazole and pimozide in children with Tourette syndrome. Pediatr Neurol. 2012 Dec;47(6):419–22. doi: http://dx.doi.org/10.1016/j.pediatrneurol.2012.08.015. PMID: 23127261.23127261
175 Yoo HK, Lee JS, Paik KW, . Open-label study comparing the efficacy and tolerability of aripiprazole and haloperidol in the treatment of pediatric tic disorders. Eur Child Adolesc Psychiatry. 2011 Mar;20(3):127–35. doi: http://dx.doi.org/10.1007/s00787-010-0154-0. PMID: 21188439.21188439
176 Storch EA, De Nadai AS, Lewin AB, . Defining treatment response in pediatric tic disorders: A signal detection analysis of the yale global tic severity scale. J Child Adolesc Psychopharmacol 2011 01 Dec;21(6):621–7. doi:http://dx.doi.org/10.1089/cap.2010.0149. PMID: 2012000755.22070181
177 Omranifard V, Najafi M, Sharbafchi MR, . Risperidone as a treatment for childhood habitual behavior. J Res Pharm Pract. 2013 Jan;2(1):29–33. doi: http://dx.doi.org/10.4103/2279-042X.114086. PMID: 24991601.24991601
178 Van Bellinghen M, De Troch C. Risperidone in the treatment of behavioral disturbances in children and adolescents with borderline intellectual functioning: a double-blind, placebo-controlled pilot trial. J Child Adolesc Psychopharmacol. 2001;11(1):5–13. doi:10.1089/104454601750143348. PMID: 11322745.11322745
179 Findling RL, Goldman R, Chiu Y, . Pharmacokinetics and tolerability of lurasidone in children and adolescents with psychiatric disorders. Clinical Therapeutics. 2015;37:2788–97 26631428
180 Ronsley R, Nguyen D, Davidson J, . Increased risk of obesity and metabolic dysregulation following 12 months of second-generation antipsychotic treatment in children: A prospective cohort study. Can J Psychiatr. 2015;60:441–50.
181 Arango C, Giraldez M, Merchan-Naranjo J, . Second-generation antipsychotic use in children and adolescents: a six-month prospective cohort study in drug-naive patients. J Am Acad Child Adolesc Psychiatry. 2014 Nov;53(11):1179–90,90.e1–4. doi: http://dx.doi.org/10.1016/j.jaac.2014.08.009. PMID: 25440308.25440308
182 Calarge CA, Nicol G, Schlechte JA, . Cardiometabolic outcomes in children and adolescents following discontinuation of long-term risperidone treatment. J Child Adolesc Psychopharmacol. 2014 Apr;24(3):120–9. doi: http://dx.doi.org/10.1089/cap.2013.0126. PMID: 24725198.24725198
183 Correll CU, Manu P, Olshanskiy V, . Cardiometabolic risk of second-generation antipsychotic medications during first-time use in children and adolescents. JAMA. 2009;302(16):1765–73. doi: 10.1001/jama.2009.1549. PMID: 19861668.19861668
184 Cuerda C, Merchan-Naranjo J, Velasco C, . Influence of resting energy expenditure on weight gain in adolescents taking second-generation antipsychotics. Clin Nutr. 2011 Oct;30(5):616–23. doi: http://dx.doi.org/10.1016/j.clnu.2011.03.00. PMID: 21492975.21492975
185 Findling RL, Kauffman RE, Sallee FR, . Tolerability and pharmacokinetics of aripiprazole in children and adolescents with psychiatric disorders: an open-label, dose-escalation study. J Clin Psychopharmacol. 2008b;28(4):441–6. doi: 10.1097/JCP.0b013e31817dd520. PMID: 18626272.18626272
186 Fleischhaker C, Heiser P, Hennighausen K, . Clinical drug monitoring in child and adolescent psychiatry: Side effects of atypical neuroleptics. J Child Adolesc Psychopharmacol. 2006;16(3):308–16. doi:10.1089/cap.2006.16.308. PMID: 16768638.16768638
187 Fraguas D, Merchan-Naranjo J, Laita P, . Metabolic and hormonal side effects in children and adolescents treated with second-generation antipsychotics. J Clin Psychiatry. 2008;69(7):1166–75. PMID: 18588363.18588363
188 Germano E, Italiano D, Lamberti M, . ECG parameters in children and adolescents treated with aripiprazole and risperidone. Prog Neuropsychopharmacol Biol Psychiatry. 2014 Jun 3;51:23–7. doi: http://dx.doi.org/10.1016/j.pnpbp.2013.10.020. PMID: 24211841.24211841
189 Pogge DL, Singer MB, Harvey PD. Rates and predictors of adherence with atypical antipsychotic medication: a follow-up study of adolescent inpatients. J Child Adolesc Psychopharmacol. 2005 Dec;15(6):901–12. doi:10.1089/cap.2005.15.901. PMID: 16379510.16379510
190 Saito E, Correll CU, Gallelli K, . A prospective study of hyperprolactinemia in children and adolescents treated with atypical antipsychotic agents. J Child Adolesc Psychopharmacol. 2004;14(3):350–8. doi:10.1089/cap.2004.14.350. PMID: 15650492.15650492
191 Alacqua M, Trifiro G, Arcoraci V, . Use and tolerability of newer antipsychotics and antidepressants: A chart review in a paediatric setting. Pharm World Sci. 2008;30(1):44–50. PMID: 17588130.17588130
192 Bastiaens L. A non-randomized, open study with aripiprazole and ziprasidone for the treatment of aggressive behavior in youth in a community clinic. Community Men Health J. 2009;45(1);73–7. doi: 10.1007/s10597-008-9154-7 PMID: 18597173.18597173
193 Bobo WV, Cooper WO, Stein CM, . Antipsychotics and the risk of type 2 diabetes mellitus in children and youth. JAMA Psychiatry. 2013 Oct;70(10):1067–75. doi: http://dx.doi.org/10.1001/jamapsychiatry.2013.2053. PMID: 23965896.23965896
194 Ebert T, Midbari Y, Shmilovitz R, . Metabolic effects of antipsychotics in prepubertal children: a retrospective chart review. J Child Adolesc Psychopharmacol. 2014 May;24(4):218–22. doi: http://dx.doi.org/10.1089/cap.2013.0116. PMID: 24816004.24816004
195 Friedlander R, Lazar S, Klancnik J. Atypical antipsychotic use in treating adolescents and young adults with developmental disabilities. Can J Psychiatry. 2001;46(8):741–5. PMID: 11692977.11692977
196 Jerrell JM, McIntyre RS. Adverse events in children and adolescents treated with antipsychotic medications. Hum Psychopharmacol. 2008 Jun;23(4):283–90. doi: http://dx.doi.org/10.1002/hup.932. PMID: 18302312.18302312
197 Khan RA, Mican LM, Suehs BT. Effects of olanzapine and risperidone on metabolic factors in children and adolescents: a retrospective evaluation. J Psychiatr Pract. 2009 Jul;15(4):320–8. doi: http://dx.doi.org/10.1097/01.pra.0000358319.81307.a5. PMID: 19625888.19625888
198 Khan SS, Mican LM. A naturalistic evaluation of intramuscular ziprasidone versus intramuscular olanzapine for the management of acute agitation and aggression in children and adolescents. J Child Adolesc Psychopharmacol. 2006;16(6):671–7. doi:10.1089/cap.2006.16.671. PMID: 17201611.17201611
199 Martin A, Landau J, Leebens P, . Risperidone-associated weight gain in children and adolescents: A retrospective chart review. J Child Adolesc Psychopharmacol. 2000;10(4):259–68. doi:10.1089/cap.2000.10.259. PMID: 2001041072.11191686
200 Migliardi G, Spina E, D’Arrigo C, . Short- and long-term effects on prolactin of risperidone and olanzapine treatments in children and adolescents. Prog Neuropsychopharmacol Biol Psychiatry. 2009;33(8):1496–501. doi: 10.1016/j.pnpbp.2009.08.009. PMID: 19706318.19706318
201 Wonodi I, Reeves G, Carmichael D, . Tardive dyskinesia in children treated with atypical antipsychotic medications. Mov Disord. 2007 Sep 15;22(12):1777–82. doi: 10.1002/mds.21618 PMID: 17580328.17580328
202 American Diabetes Association, American Psychiatric Association, American Association of Clinical Endocrinologists, . Consensus development conference on antipsychotic drugs and obesity and diabetes. J Clin Psychiatry. 2004 Feb;65(2):267–72. PMID: 15003083.15003083
203 Findling RL, Jensen PS. American Academy of Child and Adolescent Psychiatry. Practice Parameter for the use of Atypical Antipsychotic Medications in Children and Adolescents. 2012. Available at www.aacap.org
204 Edelsohn GA, Parthasarathy M, Terhorst L, . Measurement of metabolic monitoring in youth and adult Medicaid recipients prescribed antipsychotics. J Manag Care Spec Pharm. 2015 Sep;21(9):769–77, 77a–77cc. doi: 10.18553/jmcp.2015.21.9.769. PMID: 26308224.26308224
205 Morrato EH, Druss BG, Hartung DM, . Small area variation and geographic and patient-specific determinants of metabolic testing in antipsychotic users. Pharmacoepidemiol Drug Saf. 2011 Jan;20(1):66–75. doi: 10.1002/pds.2062. PMID: 21182154.21182154
206 Morrato EH, Druss B, Hartung DM, . Metabolic testing rates in 3 state Medicaid programs after FDA warnings and ADA/APA recommendations for second-generation antipsychotic drugs. Arch Gen Psychiatry. 2010 Jan;67(1):17–24. doi: 10.1001/archgenpsychiatry.2009.179. PMID: 20048219.20048219
207 Rodday AM, Parsons SK, Mankiw C, . Child and adolescent psychiatrists’ reported monitoring behaviors for second-generation antipsychotics. J Child Adolesc Psychopharmacol. 2015 May;25(4):351–61. doi: 10.1089/cap.2014.0156. PMID: 25918843.25918843
208 De Hert M, Vancampfort D, Correll CU, . Guidelines for screening and monitoring of cardiometabolic risk in schizophrenia: systematic evaluation. Br J Psychiatry. 2011 Aug;199(2):99–105. doi: 10.1192/bjp.bp.110.084665. PMID: 21804146.21804146
209 Almandil NB, Liu Y, Murray ML, . Weight gain and other metabolic adverse effects associated with atypical antipsychotic treatment of children and adolescents: a systematic review and meta-analysis. Paediatr Drugs. 2013 Apr;15(2):139–50. doi: 10.1007/s40272-013-0016-6. PMID: 23519708.23519708
210 Cohen D, Bonnot O, Bodeau N, . Adverse effects of second-generation antipsychotics in children and adolescents: a Bayesian meta-analysis. J Clin Psychopharmacol. 2012 Jun;32(3):309–16. doi: 10.1097/JCP.0b013e3182549259. PMID: 22544019.22544019
211 Maayan L, Correll CU. Weight gain and metabolic risks associated with antipsychotic medications in children and adolescents. J Child Adolesc Psychopharmacol. 2011 Dec;21(6):517–35. doi: 10.1089/cap.2011.0015. PMID: 22166172.22166172
212 Moher D, Pham B, Klassen TP, . What contributions do languages other than English make on the results of meta-analyses? J Clin Epidemiol. 2000 Sep;53(9):964–72. PMID: 11004423.11004423
213 Pham B, Klassen TP, Lawson ML, Moher D. Language of publication restrictions in systematic reviews gave different results depending on whether the intervention was conventional or complementary. J Clin Epidemiol. 2005; 58(8):769–76. PMID: 16086467.16086467
214 Ghanizadeh A. Twice-weekly aripiprazole for treating children and adolescents with tic disorder, a randomized controlled clinical trial. Ann Gen Psychiatry. 2016;15:21. PMID: 27579050.27579050
215 Safavi P, Hasanpour-Dehkordi A, AmirAhmadi M. Comparison of risperidone and aripiprazole in the treatment of preschool children with disruptive behavior disorder and attention deficit-hyperactivity disorder: A randomized clinical trial. J Adv Pharm Technol Res. 2016;7:43–7. PMID: 27144151.27144151
216 Lamberti M, Siracusano R, Italiano D, . Head-to-head comparison of aripiprazole and risperidone in the treatment of ADHD symptoms in children with autistic spectrum disorder and ADHD: a pilot, open-label, randomized controlled study. Pediatr Drugs. 2016;18: 319–328. PMID: 27278054.27278054
217 Yoon Y, Wink LK, Pedapati EV, . Weight gain effects of second-generation antipsychotic treatment in autism spectrum disorder. J Child Adolesc Psychopharmacol 2016 DOI: 10.1089/cap.2016.0049. PMID: 27389348.27389348