# Methods

The methods for this review of antipsychotics in children and young adults are based on the methods specified in the Agency for Healthcare Research and Quality (AHRQ) Methods Guide for Effectiveness and Comparative Effectiveness Reviews (Methods Guide).^45^ The main sections in this chapter reflect the elements of the protocol established for the review;^46^ this report provides a summary of the methods outlined in detail in the protocol. The methods and analyses were determined a priori, except where otherwise specified.

## Topic Refinement and Review Protocol

The American Academy of Child and Adolescent Psychiatry (AACAP) is a partner with AHRQ for this systematic review. During the topic development and refinement processes, we developed draft versions of the analytic frameworks, Key Questions (KQs), and inclusion/exclusion criteria in the form of PICOTS (populations, interventions, comparators, outcomes, timing, settings). The processes were guided by the information provided by original CER No. 39, a scan of the literature, and discussions with methods and contents experts, and Key Informants (KIs); we worked with six KIs during topic refinement. Subsequently, the analytic frameworks, KQs, and PICOTs were posted for public comment on AHRQ’s Effective Health Care Web site from June 9 through June 29, 2015. After consultation with AHRQ and responding to the public comments, we engaged a Technical Expert Panel (TEP)—including two of the KIs—to develop the systematic review protocol. The final protocol was posted on AHRQ’s Effective Healthcare Web site on December 4, 2015.^46^ The protocol was registered with the PROSPERO database (No. CRD 42016032943) on January 5, 2016. The KIs and TEP members will be identified in the front matter of the final report.

## Inclusion/Exclusion Criteria

We used the eligibility criteria outlined in the PICOTS-D as presented in Table 1. Additional details for the inclusion and exclusion criteria related to the PICOTS-D elements, including FDA-regulatory status and indications for each antipsychotic, are described in the published protocol. We provide details here for the outcomes of interest, including those considered key outcomes for assessing the strength of the body of evidence. The primary focus in KQ2 was harms across all conditions because adverse events associated with an antipsychotic are likely to be consistent regardless of the indication for which a drug is being taken; the difference in harms between conditions was treated as a subgroup of interest. We defined nonrandomized controlled trials (NRCTs) as experimental trials without random allocation but where intervention(s) are introduced, standardized, and allocated objectively [e.g., by date of birth, but not using subjective means such as patient or clinician preferences] by investigators and blinding of participants is typically possible.

Table 1 PICOTS (population, interventions, comparators, outcomes, timing, setting)

Category | Criteria
Population | Children and young adults (≤24 years) with one or more of the following conditions/issues: AD, ADHD/DICD, ASD, BD, DD, ED, OCD, PTSD, SUD, SZ, TD, or behavioral issues outside the context of a disorder (e.g., insomnia). KQ1: For each condition category, inclusion of studies enrolling ≥90 percent of patients diagnosed with the specific condition (s). KQ2: Across all conditions, inclusion of studies enrolling patients within a single or within multiple/mixed condition categories. Subpopulations based on patient characteristics: sex; age (<6 years, 6–12 years, 13–18 years, 19–24 years); race/ethnicity (i.e., % nonwhite); comorbidities/co-conditions (e.g., ADHD); history of treatment (e.g., naïve, refractory); phase and features of disorder (e.g., acute mania vs. maintenance treatment [bipolar disorder], first-episode psychosis versus treatment in context of prior episodes [schizophrenia], presence of psychosis [disorders other than schizophrenia]).
Interventions | Any FDA-approved FGA (chlorpromazine, droperidol, fluphenazine, haloperidol, loxapine, molindone, perphenazine, pimozide, prochlorperazine, thiothixene, thioridazine, trifluoperazine) Any FDA-approved SGA (aripiprazole, asenapine, brexpiprazole, cariprazine, clozapine, iloperidone, lurasidone, olanzapine, paliperidone, quetiapine, risperidone, ziprasidone) All formulations and doses eligible. Subpopulations as per clinical characteristics: presence of cotreatments (e.g., other medication, nonpharmacological therapy, as reported); medication dose.
Comparators | Placebo/no treatment, any other antipsychotic, or same antipsychotic at different dose. Exclusion of non-antipsychotic medications as comparator.
Outcomes | KQ1: intermediate and effectiveness outcomes (see following list of outcomes). KQ2: any AE and any major AEs; any or major AE limiting treatment (e.g., withdrawal due to AE); specific AEs (i.e., individual major or general AEs; see following list of outcomes)
Timing | No minimum followup duration Short term: <6 months Long term: ≥6 months-<12 months; 12 months+
Setting | Any setting
Design | Clinical trials (RCTs and NRCTs), controlled cohort studies (prospective or retrospective), controlled before-after studies (e.g., open-label extensions with comparator group, pooled analyses of individual patient-level data from one or a combination of similar trials).
Language | English

AD = anxiety disorders; ADHD/DICD = attention deficit hyperactivity disorder, or disruptive, impulse-control, or conduct disorders; AE = adverse effect; ASD = autism spectrum disorders; BD = bipolar disorder; DD = depressive disorders, ED = eating disorder; FDA = Food and Drug Adminsitration; FGA = first-generation antipsychotic; KQ = key question; NRCT = nonrandomized controlled trial; OCD = obsessive-compulsive disorder; PTSD = posttraumatic stress disorder; RCT = randomized controlled trial; SGA = second-generation antipsychotic; SUD = substance use disorder; SZ = schizophrenia and related psychosis; TD = tic disorders

### Outcomes

The intermediate and effectiveness outcomes of interest to this review are listed below, followed by the harms. We accounted for duration of response, that is, short- (< 6 months) and long-term (≥ 6 months – < 12 months; ≥ 12 months). Key outcomes assessed for the strength of the body of evidence and considered when assessing subgroup analyses are indicated by an asterisk (^*^); these key outcomes were chosen—using input from KIs our TEP—because they reflect outcomes most targeted by treatment with antipsychotics and are of relatively high importance to patients, their families, and clinicians.

#### Intermediate Outcomes

- Short-term disorder-specific (core) symptoms:
  ○ Schizophrenia and related psychoses: positive^*^ and negative symptoms^*^, disorganized behavior, impaired thought process, mood symptoms;
  ○ Autism spectrum disorders: irritability (i.e., aggression, deliberate self-injury, and temper tantrums)^*^, qualitative impairment in social interactions^*^, communication^*^, restricted repetitive and stereotyped behaviors^*^, interests, and activities;
  ○ Bipolar disorder: severity of mania^*^, anxiety, depression^*^, mood symptoms, psychotic features^*^;
  ○ Attention deficit hyperactivity disorder (ADHD) or disruptive, impulse-control, and conduct disorders (DICD): aggression^*^, negativistic, hostile and defiant behavior, externalizing behaviors^*^, impulsivity^*^;
  ○ Obsessive compulsive disorder (OCD): obsessive thoughts^*^, compulsive behavior^*^;
  ○ Substance use disorder: cravings, abstinence/substance use days^*^;
  ○ Major or persistent depressive disorder: depression^*^, irritability^*^, psychotic features (e.g., positive and negative symptoms)^*^;
  ○ Anxiety disorder: anxiety^*^, irritability^*^;
  ○ Posttraumatic stress disorder: hyperarousal^*^, avoidance behaviors^*^, intrusion^*^;
  ○ Eating disorders: weight^*^, body mass index, cognitive distortions, eating disorder attitudes and beliefs;
  ○ Tic disorders: motor and vocal tic frequency^*^ and severity^*^;
  ○ Behavioral issues outside the context of disorder or illness: aggression, agitation, anxiety, behavioral dyscontrol, irritability, mood lability, self-injurious behaviors, and sleep latency and duration.
- Short-term nonspecific or associated symptoms
  ○ Various (often composite or associated) psychiatric behaviors or symptoms (e.g., response rates^*^, anxiety in OCD, depression in tic disorders, sleep disorders, overall behaviors/symptoms in autism), and not including global assessments
- Short-term global impressions and functioning^*^
- Medication adherence
- Short-term school performance and attendance
- Short-term legal or justice system interaction (e.g., arrests, detention)
- Lifestyle behaviors (i.e., changes to diet or physical activity)

#### Effectiveness (Patient- and Family-Important) Outcomes

- Long-term (≥ 6 month followup) disorder-specific symptoms (see list above under Intermediate Outcomes)^*^
- Long-term (≥ 6 month followup) nonspecific or associated symptoms
  ○ Various (often composite or associated) psychiatric behaviors or symptoms (e.g., response rates^*^, anxiety in OCD, depression in tic disorders, sleep disorders, overall behaviors/symptoms in autism), and not including global assessments
- Long-term (≥ 6 month followup) global impressions and functioning^*^
- Growth and maturation
- Cognitive and emotional development and functioning^*^
- Suicide-related ideations or behaviors, or death by suicide^*^
- Long-term (≥ 6 month followup) school performance and attendance
- Occupational functional capacity
- Generic and specific health status and quality of life (i.e., patient and family functional status [e.g., social or relationship success, development of autonomy, and others tied to developmental level and family function], health-related quality of life, quality of life, well-being) using validated instruments^*^
- Caregiver burden/strain
- Long-term (≥ 6 month followup) legal or justice system interaction^*^
- Health care system utilization

#### Harms

Adverse effects (AEs) were examined across all conditions (KQ2). In addition to describing findings for each AE specified below, we analyzed AEs in terms of: 1) any adverse event (AE) and any AE limiting treatment (i.e., non-compliance/withdrawal rates due to AEs), and 2) major AEs and major AEs limiting treatment.

##### Major Adverse Effects^*^

- Mortality
- Cerebrovascular disease-related events
- Development of diabetes mellitus
- Diabetic ketoacidosis
- Neuroleptic malignant syndrome
- Seizures
- Tardive dyskinesia
- Cardiomyopathies
- Cardiac arrhythmias
- Agranulocytosis

##### General Adverse Effects

- Neuromotor effects (e.g., extrapyramidal symptoms including dystonia, akinesia, akathisia)^*^
- Metabolic effects (e.g., metabolic syndrome, change in body composition [weight, BMI], fasting glucose, insulin sensitivity/resistance, dyslipidemia [total cholesterol, HDL cholesterol, LDL cholesterol, triglycerides], blood pressure)^*^
- Prolactin-related effects and sexual dysfunction (e.g., hyperprolactinemia, AEs related to prolactin elevations [e.g., galactorrhea/bloody galactorrhea, hypogonadism], erectile dysfunction, infertility, oligo/amenorrhea, precocious puberty)^*^
- Agitation
- Constipation
- Somnolence^*^ and fatigue
- Elevated transaminases
- Exercise intolerance
- Discontinuation syndrome (including symptoms related to motor [e.g., withdrawal-induced dyskinesias, dystonias], autonomic (e.g., disturbed temperature regulation, nausea] and psychoses [e.g., rebound psychosis]

## Literature Search Strategy

The research librarian, in collaboration with the investigative team, revised and implemented the original search strategy to incorporate the changes to the conditions of interest. Because of the addition of several conditions, we re-ran all searches back to 1987 rather than 2010 as suggested for update searches.

We comprehensively searched the following electronic databases: Ovid MEDLINE and Ovid MEDLINE® In-Process & Other Non-Indexed Citations (1946 to Present), Cochrane Central Register of Controlled Trials via Wiley Cochrane Library (1991 to Present), EMBASE® via Ovid (1980 to 2016 Week 15), CINAHL Plus with Full Text via EBSCOhost (1937 to Present), PsycINFO® via Ovid (1987 to April Week 1 2016), ProQuest^®^ Dissertations and Theses Global (1861 to Present), and TOXLINE via The U.S. National Library of Medicine (1840s to Present). Searches were conducted between October 15^th^ and October 22^nd^, 2015 and were restricted to English language studies published since 1987. The searches of the first five databases were updated in April 2016. Using a combination of controlled vocabulary and keywords, search filters for RCTs, NRCTs, and observational studies were applied (where applicable) to the search results retrieved from the above listed databases.^47^ The search strategies for each database are located in Appendix B; the MEDLINE strategy was peer reviewed by a second librarian and adapted to accommodate the controlled vocabularies and search languages of the other databases.

Several other sources were used to obtain data from reports of studies. Reference lists of relevant systematic reviews and guidelines (identified when searching bibliographic databases), and of included studies were screened to identify potentially relevant (published or unpublished) studies. On October 26^th^ and 27^th^, 2015, we searched ClinicalTrials.gov, and the World Health Organization’s International Clinical Trials Registry Platform. We handsearched the Journal of Child and Adolescent Psychopharmacology, and the Journal of the American Academy of Child and Adolescent Psychiatry (2014–2015). Drug manufacturers and other relevant stakeholders (via AHRQ’s Scientific Resource Center) were notified of the opportunity to submit scientific information relevant to the interventions of this systematic review. We searched Drugs@FDA for Medical/Clinical and Statistical review documents; as with the original CER, we only searched regulatory documents containing harm data for patients 18 years of age or younger.

All results of the database searches were imported into an EndNote^®^ database (Thomson Reuters, New York, NY). Results from other searches were documented in a Microsoft Excel database (Microsoft Corp., Redmond, WA). We tracked the screening and selection results in EndNote.

## Study Selection

For the database searches, two reviewers independently screened the titles and abstracts (when available) using broad inclusion/exclusion criteria. One reviewer conducted all other searches outlined in the above section. The full text of all studies classified as “include/unsure” or identified after screening the reference citations were retrieved for full review; two reviewers independently assessed eligibility using a standard form that outlined the inclusion and exclusion criteria. Disagreements on final inclusion of all studies were resolved through consensus or third party adjudication.

## Data Abstraction and Data Management

One review team member extracted data for each study, and a senior level team member verified all data. Data was extracted on elements relevant to the Key Questions, including population characteristics, study characteristics (including funding source), descriptions of the intervention(s) and comparator(s)―including dose, route of administration, etcetera―analytic details including subgroup analysis on treatment modification, and outcomes including outcome type, timing and definitions. As done for the original CER, when there were multiple publications associated with a study we considered the earliest report of the main (primary) outcome data to be the primary data source. We extracted data from the primary source first and then add outcome data reported in the secondary/associated publications and data sources (e.g., FDA reports). We referenced the primary source throughout the evidence report; all associated literature was tabulated for reference.

Benefit and harm data were extracted as reported by study authors; for example, we included relevant author-defined outcomes (such as percentage of participants gaining ≥7% body weight, remission, relapse, withdrawal due to lack of efficacy/response) as long as these accounted for benefit and harm outcomes of interest. A wide variety of checklists and scales were used to assess symptomatology in patients. In various instances (e.g., hyperactivity, aggression) we used subscale items on one or more questionnaires, rather than their overall composite scores, to capture the outcomes of interest with more specificity. For harms, we focused on outcome metrics most likely to be relevant to decision making; for example, we focused on reports of abnormal serum lipids rather than mean changes in serum levels which may not reflect a clinically relevant degree of harm.

We recorded intention-to-treat results, if possible. For continuous outcomes measures, we extracted (by arm) the mean baseline and endpoint or change scores, standard deviations (SD) or other measure of variability, and number analyzed. If necessary, we approximated means by medians. If SD were not given, they were computed from p-values, 95% confidence intervals (95% CIs), z-statistics, or t-statistics. If computation was not possible they were estimated from upper bound p-values, ranges, inter-quartile ranges, or (as a last resort) by imputation using the largest reported SD from the other studies in the same meta-analysis. When computing SDs for change from baseline values, we assumed a correlation of 0.5. For dichotomous outcomes, we reported counts or proportions, and sample size, by study arm. When there was data for more than one timepoint within each of our followup strata (e.g., results for 1- and 3-month followup were both within our 0 to <6-month stratum) we used the longest followup duration.

Only numerical data for AEs was extracted; that is, we made no assumptions on lack or presence of an AE if it was not reported. We extracted data (taking care to avoid duplication with other study reports) on harms from trial registries and regulatory agency reports of pediatric trials. For each major AE, we reported the number of studies that provided data for the AE. We also reported summary totals of the number of individuals in the medication groups who were reported to have experienced the event and the total number of patients in the medication groups in relevant trials.

Data on within-study subgroup analysis was collected, including: subgroups (independent variables), the type of analysis (e.g., subgroup/stratified or regression analysis), the outcomes assessed (dependent variables), and the authors’ conclusions. We collected data suitable for all patient and clinical characteristics for performing our own subgroup analyses based on study-level data.

## Assessment of Methodological Quality of Individual Studies

Two experienced reviewers independently assessed the methodological quality of all original and new studies and resolved discrepancies through consensus. We re-assessed original studies because of changes to guidance in the EPC program made subsequent to the original CER. For RCTs and NRCTs we used the Cochrane Collaboration Risk of Bias tool,^48^ with some modification based on EPC Methods guidance.^45^ We did not assess selective outcome reporting at the study level, since this was considered within the reporting bias domain of our assessment of the strength of evidence (SOE) for individual outcomes across studies.^49^ The “other” domain included considerations of baseline imbalances between study groups and whether the study protocol included a wash-out period for patients who were not drug naïve. The overall assessment was based on the responses to individual domains. If one or more individual domains were assessed as having a high risk of bias, the overall score was rated as high risk of bias. The overall risk of bias was considered low only if all components were rated as having a low risk of bias. The risk of bias for all other studies was rated as medium. Information was collected for each study on the source of funding.

For cohort studies, we used the Newcastle-Ottawa Quality Assessment Scale.^50^ The scale comprises of seven items that evaluate three domains of quality/risk of bias: sample selection, comparability of cohorts, and assessment of outcomes. Each item that is adequately addressed is awarded one star, except for the “comparability of cohorts” item, for which a maximum of two stars can be given. We considered a total score of 6 to 8 stars to indicate high quality/low risk of bias, 4 or 5 stars to indicate moderate quality/medium risk of bias, and 3 or fewer stars to indicate poor quality/high risk of bias.

## Data Synthesis

For each condition we summarized the characteristics of included studies qualitatively and present important features of the study populations, study designs, interventions, comparators, and reported outcomes in summary tables. For each KQ, we synthesized data in the following order based on type of comparison (as possible depending on data): aggregate (across drug class) data for FGAs versus SGAs, individual FGAs versus SGAs, within-class comparisons between individual FGAs and individual SGAs (other drug or dose), and then individual and aggregate data for FGAs versus placebo and SGAs versus placebo.

Various approaches to synthesizing the evidence are available including direct pairwise meta-analysis and methods that combine direct and indirect evidence (i.e., network meta-analysis or mixed treatment comparisons).^51–52^ The summary effect from direct comparisons (e.g., an SGA vs. placebo, one SGA or FGA vs. another SGA or FGA) for one outcome at a similar timepoint is meaningful as a first approach. However, such an approach does not allow for comparisons between drugs that may not have much direct evidence (e.g., drug A was compared to drug B and C, but drugs B and C were not been directly compared). Where feasible, we conducted network meta-analyses, as described below.

In the event that results from studies were not combined using meta-analysis, a narrative summary of the results is presented and precision is indicated using 95% CIs from the individual studies.

### Pairwise and Network Meta-Analyses

For pairwise meta-analyses, we employed a Bayesian random effects model using WinBUGs software.^53^ This approach models uncertainty in between-study variability and was used in place of the more traditionally employed Der Simonian-Laird approach, which has been shown to result in a high number of statistically significant results (falsely high precision) especially in the face of heterogeneity and few studies.^54^ We used this approach when more than two studies reported on the same outcome and comparisons; when two studies are combined using this model the precision in the effect estimate is very often too wide to provide, in our opinion, any benefit from the analysis. When different outcomes were considered to measure the same construct (e.g., different subscores of hyperactivity) we combined the results (at followup) of multiple scores using a standardized mean difference (SMD); in this way we were able to use as many studies as possible to capture effect estimates for our outcomes. When the SMD was not used because of reporting by multiple studies using the same measurement scale (enabling calculation of a mean difference [MD]), change scores were preferred over followup scores and we combined these two when necessary. We reported MD, SMD, or relative risks/risk ratios (RR) with corresponding 95 percent credible intervals (95% CrI; Bayesian approaches provide variances using credible rather than confidence intervals, interpretable as the range of values within which there is a 95% chance of finding the true value of the effect). Non-informative priors were selected for estimated parameters. A Markov chain Monte Carlo (MCMC) simulation was then run, using a burn in sample of 20,000 iterations (which were discarded) followed by 200,000 iterations which were used to estimate the model parameters. A description of the model and code is included in Appendix G.

In general, we combined results from studies when there was sufficient clinical (i.e., population characteristics, interventions, outcome ascertainments) and methodological (i.e., study design, conduct and quality) similarities. We often started with combing all studies within a condition category and then used our a priori defined list of patient and intervention subgroups to explore the heterogeneity. For intermediate and effectiveness outcomes we considered combining results from RCTs with NRCTS, but not with cohort studies. For harm outcomes we combined data from all study designs, for the following reasons: 1) empirical evidence has found no difference in estimates of harms between meta-analyses of RCT and cohort study designs;^55^ 2) a major contributor to bias on harms from observational studies is confounding by indication (e.g., differential prescriptions based on beliefs/knowledge about factors related to development of harms) which we did not believe was an important threat in studies examining unanticipated harms in (mostly) treatment naïve children; and 3) cohort studies are commonly recognized as contributing valuable, relatively high-quality evidence applicable to real-world settings. To avoid making conclusions from these analyses without carefully considering possible biases, we identified important potential confounders on which to assess the findings for heterogeneity and also extracted data from all studies on their own subgroup analysis for patient and clinical treatment modifiers. Where there are at least eight studies in a meta-analysis, we analyzed publication bias both visually using the funnel plot and quantitatively using Egger’s test.^56^

Since we were interested in comparisons within and across classes of FGAs and SGAs, approaches that considered inferences from indirect data were suitable. Rather than providing a simple pair-wise analysis of similar comparisons (e.g., SGAs vs. placebo) through standard meta-analysis, a network meta-analysis allows for simultaneous evaluation of a suite of comparisons while still preserving the within-study randomization. A network of different comparisons is constructed (with “nodes” representing the different medications) to consider both direct evidence from comparisons of similar interventions/nodes and indirect evidence from comparisons where one intervention is in common, but not all (e.g., intervention A vs. placebo, and intervention B vs. placebo infer knowledge about intervention A vs. intervention B). This analysis was conducted for the outcomes of weight and body mass index; other outcomes were often only reported by a single study within a particular comparison, such that the validity of using this approach for these was questionable.

When using this Bayesian network meta-analysis approach, all unknown parameters were given non-informative prior distributions and were estimated using MCMC methods in WinBUGS software. The model was run for 220,000 iterations, with the first 20,000 samples conservatively discarded as burn-in, leaving 200,000 for inference. We conducted convergence diagnostics (i.e., convergence verified using autocorrelation, paying particular attention to prior distributions on between study variance parameter) and assessed the fit of the models by monitoring the deviance parameters; the analyses were also checked for consistency by contrasting direct and indirect estimates in every closed loop of the networks with a display of the results in plots.^57^ We obtained estimates of the treatment effects and rank probabilities for each treatment strategy (e.g., probability that a particular drug is the “worst” for the particular outcome). Findings from the network meta-analysis are considered fairly observational in nature and were compared with other more direct findings. The model structure and code are included in Appendix G.

In addition to multiple comparisons, meta-analytical approaches have been developed to incorporate multiple outcomes even within a network meta-analysis.^58^ One example is when most, but not all, studies report on a set of specific measurement tools or values but others only report a subset of the values. A multivariate approach can allow for the borrowing of strength across the entire set of relevant studies, and enable the correlation between outcomes (both within and between studies) to be directly estimated. We had anticipated this approach may have been suitable for enhancing our ability to report on some outcomes, particularly on harms, which are not reported on by all studies. The only outcomes that were reported on by enough studies to have missing data for a minority were weight and BMI, but since these variables are mathematically correlated (i.e., BMI is function of weight and height) it would not be appropriate to include them in such a model.^59^ Other groups of outcomes (e.g., dyslipidemia, fasting glucose) were not all reported by enough studies or by enough different comparisons (i.e., mostly through placebo-controlled studies) to enable a valid model.

### Analysis of Subgroups

Our primary approach to answer parts (a) and (b) of each KQ was to record any within-study subgroup analyses performed by study investigators using individual patient data; these results preserved the within-study randomization. Because these results are often based on diverse methodology and may be difficult to interpret across the body of evidence, we also performed our own “across study” subgroup analyses using study-level data on our variables of interest (e.g., phase of treatment, treatment history of participants), where possible. For the benefit outcomes, the number of studies within any given comparison was too few to perform formal statistical approaches such as meta-regression; for these outcomes we performed sensitivity analysis of the results of the pairwise meta-analyses by subgroup variables, and/or commented on observations about the differences in effects and heterogeneity between studies based on subgroup variables of interest. Since there were more studies for KQ2 on several harm outcomes, we employed univariate Bayesian meta-regression analyses for four key harm outcomes (weight, weight gain of greater than 7%, somnolence, incidence of any extrapyramidal symptoms) in terms of each study’s mean patient age, sex, antipsychotic treatment history (i.e., % treatment naïve), and treatment duration. These analyses relied on study-level data, such that the results should be considered observational in nature. We used the same prior distributions (adding a non-informative uniform prior for the regression coefficient), burn in iterations, and estimate iterations as were used in the primary meta-analyses (Appendix G contains details). Because of the finding that treatment duration was a statistically significant modifier for weight gain, we also performed adjusted network meta-analyses for weight and BMI using this study-level variable.

## Grading the Strength of the Body of Evidence

We followed the Methods Guide and updated guidance^50^ to evaluate the strength of the body of evidence (SOE) for the key outcomes and comparisons. The body of evidence was graded by one reviewer, and reviewed by a second reviewer. Disagreements were resolved through discussion or by consulting with a third reviewer, as needed. Tables of findings were generated for all outcomes and comparisons that had greater than insufficient SOE.

Trials and observational evidence were graded separately for each outcome-comparison pair, with the overall SOE incorporating both study designs, if applicable. We assessed the SOE based on five core domains: study limitations, consistency, directness, precision, and reporting bias. Our protocol contains details for these assessments and we only expand on our assessments of precision here to provide explanation for many of our decisions. We assessed precision (precise or imprecise) first on the basis of sample size. For continuous outcomes, more than 400 total enrolled patients are generally considered to offer precise data based on adequate power to detect a 0.2 standardized effect size;^60^ we estimated that studies having as few as 200 patients could offer precise estimates of effect supporting a particular direction (but not magnitude) of effect. For binary data with our harm outcomes, the sufficiency of the sample size was based on event rates in the control group.^60^ That is, when fewer than 5 percent of patients experienced the event we required more than 2000 patients to represent adequate power to detect a difference between groups. When sample size was considered adequate, we further assessed precision based on the magnitude of the effects represented by the effect estimate and limits of the credible/confidence intervals. For outcomes where thresholds of clinically significant values were found in the literature, or estimated using the study reports or by our clinical investigators, we downgraded the precision domain if the 95% CrI (or the 95% CI in cases where results were not combined) crossed both no difference (0 MD or 1.0 RR) and the threshold; if a 95% CrI was very wide we downgraded the imprecision domain twice. In other words, when a CrI/CI around an effect estimate was not statistically significant but included values that may be clinically significant for many patients, we cannot rule out the possibility of a benefit for this outcome and therefore rated down for precision.

We rated the body of evidence for each outcome and comparison using four SOE grades which indicate our level of confidence that the evidence reflects the true (direction of) effect for the major comparisons of interest:

High | We are very confident that the estimate of effect lies close to the true effect for this outcome. The body of evidence has few or no deficiencies. We believe that the findings are stable, i.e., another study would not change the conclusions.
Moderate | We are moderately confident that the estimate of effect lies close to the true effect for this outcome. The body of evidence has some deficiencies. We believe that the findings are likely to be stable, but some doubt remains.
Low | We have limited confidence that the estimate of effect lies close to the true effect for this outcome. The body of evidence has major or numerous deficiencies (or both). We believe that additional evidence is needed before concluding either that the findings are stable or that the estimate of effect is close to the true effect.
Insufficient | We have no evidence, we are unable to estimate an effect, or we have no confidence in the estimate of effect for this outcome. No evidence is available or the body of evidence has unacceptable deficiencies, precluding reaching a conclusion.

## Interpretations Throughout Report

We chose to use standard wording to describe how we interpreted the SOE and the magnitude of the effects for key outcomes;^61^ our Key Points and tables of the strength of evidence (results chapter) and discussion relay these interpretations, while our Detailed Findings sections provide the exact fidnings regardless of their strength of evidence. For findings supported by high, moderate, low, and insufficient SOE (for which we similar confidence in the results) we use “will”, “probably/likely”, “may/appears to”, and “not known” in our textual descriptions of the results. Related to magnitude of effects, when the evidence showed effects that would be considered by many patients and practitioners to be either clinically important or small, we use “increase/improve/decrease/worsen” (as suitable) or “increase/improve/decrease/worsen slightly/a small extent”, respectively; when there appears to be no difference in effect, we use “makes little or no difference.”

## Applicability

We assessed the applicability of the findings with respect to our PICOTS elements. We summarized common features of the study populations and documented diagnoses. We considered patient ages, treatment histories, co-occurring diagnoses, and symptom severity reported in the included studies and the degree to which the populations studied reflect the target populations for practice.

## Peer Review and Public Commentary

Apart from review by members of our TEP, experts in psychiatry, developmental and behavioral health, and statistics, and individuals representing stakeholder and user communities were invited to provide external peer review of this report; AHRQ and an EPC Associate Editor also provided comments. The draft report was posted on AHRQ’s Effective Healthcare website for 4 weeks to elicit public comment. We addressed all reviewer comments, revising the text as appropriate, and documented everything in a disposition of comments report that will be made available 3 months after the Agency posts the final report on the AHRQ Effective Healthcare website.